# 1 BACKGROUND

## 1.1 INTRODUCTION

This Toxicological Review critically evaluates the publicly available studies on formaldehyde (inhalation) to identify its adverse health effects and to characterize exposure-response relationships. This assessment is prepared under the auspices of the U.S. Environmental Protection Agency’s (EPA’s) Integrated Risk Information System (IRIS) Program. IRIS assessments are not regulations, but they provide a critical part of the scientific foundation for decisions made in EPA program and regional offices to protect public health.

Assessment development was based on EPA guidelines as well as standard IRIS procedures (U.S. EPA, 2020) that were reviewed by the National Academy of Sciences, Engineering, and Medicine (NASEM) (NASEM, 2021). In 1990 and 1991, an oral reference dose (RfD) (reference value for ingested formaldehyde) and an inhalation unit risk (IUR) value for cancer, respectively, were developed for formaldehyde. A previous draft of the inhalation assessment was developed between 1998 and 2010. That document was reviewed by an external peer-review panel convened by the National Research Council (NRC) between June 2010 and April 2011 (NRC, 2011). The newly developed, current assessment addresses the comments from the NRC panel on that prior draft (see Appendix D of the external review draft [https://iris.epa.gov/document/&deid=248150]), as well as comments provided during review of this document (see Appendix F).

For additional information about this assessment or for general questions regarding IRIS, please visit the IRIS website (www.epa.gov/iris).

## 1.2 OVERVIEW OF BACKGROUND INFORMATION ON FORMALDEHYDE

The brief overview below (and the corresponding information in Appendix A) is provided to introduce potentially useful context for this assessment. These summaries do not provide comprehensive descriptions of the available information on these topics and are not intended for use in decision purposes. Readers are encouraged to refer to source materials cited below, more recent publications on these topics, and specific assessments on these topic areas.

### 1.2.1 Summary of Chemical Properties and Uses

Formaldehyde (CASRN 50-00-0) is an aliphatic aldehyde noted for its reactivity and versatility as a chemical intermediate. At room temperature, pure formaldehyde is a colorless gas with a strong, pungent, and irritating odor. Formaldehyde is readily soluble in water, alcohols, ether, and other polar solvents. Due to its chemical properties (see Appendix A.1 for additional details), formaldehyde is widely used in both commercial and industrial settings. Based on EPA’s Chemical Data Reporting, the national production volume for formaldehyde was 3.9 billion lb/year in 2011 and between 1 and 5 billion lbs/year for 2012 through 2015 (https://chemview.epa.gov/chemview/#).

Products containing formaldehyde are widespread in industry and in the home (see Appendix A.2). Approximately 55% of the consumption of formaldehyde is in the production of industrial resins (NTP, 2010). Formaldehyde is used in plywood adhesives, surface coatings, molding compounds, laminates, phenolic thermosetting, resin curing agents, and other products (IPCS, 1989). Formaldehyde is used in smaller quantities for the preservation and embalming of biological specimens. It is also used as a germicide, an insecticide, and a fungicide in some products. Some industries with the greatest potential for exposure to the workforce include health services, business services, printing and publishing, chemical manufacturing, garment production, beauty salons, and furniture manufacturing (IARC, 1995).

### 1.2.2 Summary of Human Inhalation Exposure

Generally, formaldehyde levels are higher in the indoor environment than in ambient air. Indoor sources of formaldehyde in air include building materials and household products (e.g., volatilization from pressed wood products, carpets, fabrics, insulation, permanent-press clothing, latex paint), as well as household sources of combustion (e.g., gas burners, kerosene heaters, cigarettes) (WHO, 2010). Median indoor air concentrations in some European countries in both commercial and residential buildings ranged from 10 to 50 μg/m^3^ (Sarigiannis et al., 2011; Salthammer et al., 2010). Indoor average formaldehyde concentrations reported since 2000 in U.S. and Canadian conventional homes ranged from 12 to 39 μg/m^3^ (see Appendix A.3). For example, a large study of 398 homes in Los Angeles, CA, Houston, TX, and Elizabeth, NJ, between 1999 and 2001 reported mean (±SD) formaldehyde levels of 22 ± 7.1 µg/m^3^ (Weisel et al., 2005). Higher levels are found in mobile homes and trailers.

In 2018, annual site averages of formaldehyde concentrations outdoors ranged from 0.25 − 11.06 μg/m^3^ (0.20−9.01 ppb), with an overall annual site average concentration of 2.97 μg/m^3^ (2.42 ppb) (EPA’s Ambient Monitoring Archive for HAPs, which includes data from the Air Quality System database and other data sources at https://www.epa.gov/amtic/amtic-air-toxics-data-ambient-monitoring-archive). Under the National-Scale Air Toxics Assessment (NATA) program, EPA has conducted an emissions inventory for a variety of hazardous air pollutants (HAPs), including formaldehyde. NATA uses the emissions inventory data to model nationwide air concentrations/exposures (https://www.epa.gov/national-air-toxics-assessment). The most recent NATA data are for 2014. The results of the 2014 ambient air concentration modeling for formaldehyde suggest that county mean air levels range from 0.1 to 2.78 µg/m^3^ with a national mean of 1.3 µg/m^3^ [personal communication to EPA (Palma, 2018)].

Although not final, a March 15, 2024, public draft TSCA risk evaluation includes formaldehyde exposure assessments (note: IRIS assessments do not include exposure assessments). While preliminary, the draft TSCA risk evaluation cites studies supporting estimates similar to those described above. Namely, the draft estimates that the median formaldehyde concentration in U.S. homes is approximately 20 µg/m^3^ and, using monitoring data from 2023, U.S. formaldehyde concentrations in outdoor air are estimated to have a median formaldehyde concentration of 1.88 µg/m^3^. Please consult the EPA website for updates and release of the finalized TSCA risk evaluation (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-evaluation-formaldehyde).