# REFERENCES

Abrams, WR; Kallen, RG. (1976). Equilibria and kinetics of N-hydroxymethylamine formation from aromatic exocyclic amines and formaldehyde. Effects of nucleophilicity and catalyst strength upon mechanisms of catalysis of carbinolamine formation¹. J Am Chem Soc 98: 7777–7789. 10.1021/ja00440a052.23320306
Abramson, MJ; Perret, JL; Dharmage, SC; McDonald, VM; McDonald, CF. (2014). Distinguishing adult-onset asthma from COPD: a review and a new approach [Review]. Int J Chron Obstruct Pulmon Dis 9: 945–962. 10.2147/COPD.S46761.25246782
Abreu, M, d; Neto, AC; Carvalho, G; Casquillo, NV; Carvalho, N; Okuro, R; Ribeiro, GC; Machado, M; Cardozo, A; Silva, AS; Barboza, T; Vasconcellos, LR; Rodrigues, DA; Camilo, L; Carneiro, L; Jandre, F; Pino, AV; Giannella-Neto, A; Zin, WA; Corrêa, LH; Souza, MN; Carvalho, AR. (2016). Does acute exposure to aldehydes impair pulmonary function and structure? Respir Physiol Neurobiol 229: 34–42. 10.1016/j.resp.2016.04.002.27102012
ACGIH (American Conference of Governmental Industrial Hygienists). (2001). Acetaldehyde [TLV/BEI]. In Documentation of the threshold limit values and biological exposure indices (7th ed., pp. A1–A5). Cincinnati, OH.
Acheson, ED; Barnes, HR; Gardner, MJ; Osmond, C; Pannett, B; Taylor, CP. (1984a). Cohort study of formaldehyde process workers [Letter]. Lancet 2: 403. 10.1016/s0140-6736(84)90568-3.
Acheson, ED; Gardner, MJ; Pannett, B; Barnes, HR; Osmond, C; Taylor, CP. (1984b). Formaldehyde in the British chemical industry: An occupational cohort study. Lancet 323: 611–616. 10.1016/S0140-6736(84)91007-9.
Adams, DO; Hamilton, TA; Lauer, LD; Dean, JH. (1987). The effect of formaldehyde exposure upon the mononuclear phagocyte system of mice. Toxicol Appl Pharmacol 88: 165–174. 10.1016/0041-008x(87)90002-0.3564036
Aglan, MA; Mansour, GN. (2018). Hair straightening products and the risk of occupational formaldehyde exposure in hairstylists. Drug Chem Toxicol 43: 1–8. 10.1080/01480545.2018.1508215.30208742
Ahmed, S; Tsukahara, S; Tin-Tin-Win-Shwe; Yamamoto, S; Kunugita, N; Arashidani, K; Fujimaki, H. (2007). Effects of low-level formaldehyde exposure on synaptic plasticity-related gene expression in the hippocampus of immunized mice. J Neuroimmunol 186: 104–111. 10.1016/j.jneuroim.2007.03.010.17434604
Ahn, KH; Kim, SK; Lee, JM; Jeon, HJ; Lee, DH; Kim, DK. (2010). Proteomic analysis of bronchoalveolar lavage fluid obtained from rats exposed to formaldehyde. J Health Sci 56: 287–295. 10.1248/jhs.56.287.
Akbar-Khanzadeh, F; Mlynek, JS. (1997). Changes in respiratory function after one and three hours of exposure to formaldehyde in non-smoking subjects. Occup Environ Med 54: 296–300. 10.1136/oem.54.5.296.9196449
Akbar-Khanzadeh, F; Vaquerano, MU; Akbar-Khanzadeh, M; Bisesi, MS. (1994). Formaldehyde exposure, acute pulmonary response, and exposure control options in a gross anatomy laboratory. Am J Ind Med 26: 61–75. 10.1002/ajim.4700260106.8074125
Al-Saraj, AA. (2009). Teratogenic effect of formaldehyde in rabbits. Iraqi Journal of Veterinary Sciences 23: 1–4.
Alarie, Y. (1981). Toxicological evaluation of airborne chemical irritants and allergens using respiratory reflex reactions. In BKJ Leong (Ed.), Inhalation toxicology and technology (pp. 207–231). Ann Arbor, MI: Ann Arbor Science Publishers, Inc.
Albert, M; Garcia, BC; Kuhnert, C; Peschla, R; Maurer, G. (2000). Vapor-liquid equilibrium of aqueous solutions of formaldehyde and methanol. AIChE J 46: 1676–1687. 10.1002/aic.690460818.
Albert, RE; Sellakumar, AR; Laskin, S; Kuschner, M; Nelson, N; Snyder, CA. (1982). Gaseous formaldehyde and hydrogen chloride induction of nasal cancer in the rat. J Natl Cancer Inst 68: 597–603.6951075
Alderson, T. (1967). Induction of genetically recombinant chromosomes in the absence of induced mutation. Nature 215: 1281–1283.6052731
Alexandersson, R. (1988). Decreased lung function and exposure to formaldehyde in the wood working industry. A five-year follow-up. Arh Hig Rada Toksikol 39: 421–424.3273133
Alexandersson, R; Hedenstierna, G. (1988). Respiratory hazards associated with exposure to formaldehyde and solvents in acid-curing paints. Arch Environ Health 43: 222–227. 10.1080/00039896.1988.9934937.3260092
Alexandersson, R; Hedenstierna, G. (1989). Pulmonary function in wood workers exposed to formaldehyde: A prospective study. Arch Environ Health 44: 5–11. 10.1080/00039896.1989.9935865.2916856
Alexandersson, R; Hedenstierna, G; Kolmodin-Hedman, B. (1982). Exposure to formaldehyde: effects on pulmonary function. Arch Environ Health 37: 279–284. 10.1080/00039896.1982.10667579.7138077
Amdur, MO. (1960). The response of guinea pigs to inhalation of formaldehyde and formic acid alone and with a sodium chloride aerosol. Int J Environ Pollut 3: 201–220.
Amiri, A; Turner-Henson, A. (2017). The roles of formaldehyde exposure and oxidative stress in fetal growth in the second trimester. J Obstet Gynecol Neonatal Nurs 46: 51–62. 10.1016/j.jogn.2016.08.007.
An, J; Li, F; Qin, Y; Zhang, H; Ding, S. (2019). Low concentrations of FA exhibits the Hormesis effect by affecting cell division and the Warburg effect. Ecotoxicol Environ Saf 183: 109576. 10.1016/j.ecoenv.2019.109576.31509928
Anandarajan, V; Noguchi, C; Oleksak, J; Grothusen, G; Terlecky, D; Noguchi, E. (2020). Genetic investigation of formaldehyde-induced DNA damage response in Schizosaccharomyces pombe. Curr Genet 66: 593–605. 10.1007/s00294-020-01057-z.32034465
Andersen, I. (1979). Formaldehyde in the indoor environment - health implications and the setting of standards. In PO Fanger; O Valbjorn (Eds.), Indoor climate: Effects on human comfort, performance, and health in residential, commercial, and light-industry buildings (pp. 65–87). Copenhagen, Denmark: Danish Building Research Institute.
Andersen, I; Molhave, L. (1983). Controlled human studies with formaldehyde. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 154–165). Washington, DC: Hemisphere Publishing.
Andersen, ME; Clewell, HJ; Bermudez, E; Dodd, DE; Willson, GA; Campbell, JL; Thomas, RS. (2010). Formaldehyde: integrating dosimetry, cytotoxicity, and genomics to understand dose-dependent transitions for an endogenous compound. Toxicol Sci 118: 716–731. 10.1093/toxsci/kfq303.20884683
Andersen, ME; Clewell, HJ, III; Bermudez, E; Willson, GA; Thomas, RS. (2008). Genomic signatures and dose-dependent transitions in nasal epithelial responses to inhaled formaldehyde in the rat. Toxicol Sci 105: 368–383. 10.1093/toxsci/kfn097.18499655
Anderson, D; Yu, TW; Phillips, BJ; Schmezer, P. (1994). The effect of various antioxidants and other modifying agents on oxygen-radical-generated DNA damage in human lymphocytes in the COMET assay. Mutat Res 307: 261–271. 10.1016/0027-5107(94)90300-x.7513806
Andersson, B; Eriksson, B; Falsen, E; Fogh, A; Hanson, LA; Nylén, O; Peterson, H; Svanborg Edén, C. (1981). Adhesion of Streptococcus pneumoniae to human pharyngeal epithelial cells in vitro: differences in adhesive capacity among strains isolated from subjects with otitis media, septicemia, or meningitis or from healthy carriers. Infect Immun 32: 311–317.7216490
Andersson, DA; Gentry, C; Moss, S; Bevan, S. (2008). Transient Receptor Potential A1 Is a Sensory Receptor for Multiple Products of Oxidative Stress. J Neurosci 28: 2485–2494. 10.1523/JNEUROSCI.5369-07.2008.18322093
Andersson, M; Agurell, E; Vaghef, H; Bolcsfoldi, G; Hellman, B. (2003). Extended-term cultures of human T-lymphocytes and the comet assay: a useful combination when testing for genotoxicity in vitro? Mutat Res 540: 43–55. 10.1016/S1383-5718(03)00169-4.12972057
Andjelkovich, DA; Janszen, DB; Brown, MH; Richardson, RB; Miller, FJ. (1995). Mortality of iron foundry workers: IV. Analysis of a subcohort exposed to formaldehyde. J Occup Environ Med 37: 826–837. 10.1097/00043764-199507000-00012.7552467
Ankley, GT; Bennett, RS; Erickson, RJ; Hoff, DJ; Hornung, MW; Johnson, RD; Mount, DR; Nichols, JW; Russom, CL; Schmieder, PK; Serrrano, JA; Tietge, JE; Villeneuve, DL. (2010). Adverse outcome pathways: A conceptual framework to support ecotoxicology research and risk assessment [Review]. Environ Toxicol Chem 29: 730–741. 10.1002/etc.34.20821501
Annesi-Maesano, I; Hulin, M; Lavaud, F; Raherison, C; Kopferschmitt, C; de Blay, F; Charpin, DA; Denis, C. (2012). Poor air quality in classrooms related to asthma and rhinitis in primary schoolchildren of the French 6 Cities Study. Thorax 67: 682–688. 10.1136/thoraxjnl-2011-200391.22436169
Apfelbach, R; Weiler, E. (1991). Sensitivity to odors in wistar rats is reduced after low-level formaldehyde-gas exposure. Naturwissenschaften 78: 221–223. 10.1007/bf01136085.1852218
Appelman, LM; Woutersen, RA; Zwart, A; Falke, HE; Feron, VJ. (1988). One-year inhalation toxicity study of formaldehyde in male rats with a damaged or undamaged nasal mucosa. J Appl Toxicol 8: 85–90. 10.1002/jat.2550080204.3379235
Arican, RY; Sahin, Z; Ustunel, I; Sarikcioglu, L; Ozdem, S; Oguz, N. (2009). Effects of formaldehyde inhalation on the junctional proteins of nasal respiratory mucosa of rats. Exp Toxicol Pathol 61: 297–305. 10.1016/j.etp.2008.09.005.18996001
Armstrong, RW; Imrey, PB; Lye, MS; Armstrong, MJ; Yu, MC; Sani, S. (2000). Nasopharyngeal carcinoma in Malaysian Chinese: occupational exposures to particles, formaldehyde and heat. Int J Epidemiol 29: 991–998. 10.1093/ije/29.6.991.11101539
Arslan-Acaroz, D; Bayşu-Sozbilir, N. (2020). Ameliorative effect of boric acid against formaldehyde-induced oxidative stress in A549 cell lines. Environ Sci Pollut Res Int 27: 4067–4074. 10.1007/s11356-019-06986-y.31823256
Asgedom, AA; Bratveit, M; Moen, BE. (2019). High Prevalence of Respiratory Symptoms among Particleboard Workers in Ethiopia: A Cross-Sectional Study. Int J Environ Res Public Health 16. 10.3390/ijerph16122158.
Askar, EM; Halloull, NM. (2018). Formaldehyde-induced neurotoxicity in rat cerebellar cortex and possible protective effects of fatty acids from omega 3 and wheat germ oil supplement: a histopathological and biochemical study. J Histotechnol 41: 79–87. 10.1080/01478885.2018.1458176.
Aslan, H; Songur, A; Tunc, AT; Ozen, OA; Bas, O; Yagmurca, M; Turgut, M; Sarsilmaz, M; Kaplan, S. (2006). Effects of formaldehyde exposure on granule cell number and volume of dentate gyrus: a histopathological and stereological study. Brain Res 1122: 191–200. 10.1016/j.brainres.2006.09.005.17011527
ATSDR (Agency for Toxic Substances and Disease Registry). (1999). Toxicological profile for formaldehyde [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. http://www.atsdr.cdc.gov/toxprofiles/tp111.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2007). Health consultation: Formaldehyde sampling at FEMA temporary housing units, Baton Rouge, Louisiana. Atlanta, GA. http://www.atsdr.cdc.gov/HAC/PHA/fema_housing_formaldehyde/formaldehyde_report_0507.pdf.
ATSDR (Agency for Toxic Substances and Disease Registry). (2008). Draft for toxicological profile for formaldehyde [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service.
Attia, D; Mansour, N; Taha, F; El Dein, AS. (2014). Assessment of lipid peroxidation and p53 as a biomarker of carcinogenesis among workers exposed to formaldehyde in cosmetic industry. Toxicol Ind Health 32: 1097–1105. 10.1177/0748233714547152.25193344
Auerbach, C; Moser, H. (1953a). An analysis of the mutagenic action of formaldehyde-food. I. Sensitivity of Drosophila germ cells. MGG Mol gen genet 85: 479–504. 10.1007/BF00308298.
Auerbach, C; Moser, H. (1953b). Analysis of the mutagenic action of formaldehyde food. II. The mutagenic potentialities of the treatment. MGG Mol gen genet 85: 547–563. 10.1007/BF00308300.
Auerbach, C; Moutschen-Dahmen, M; Moutschen, J. (1977). Genetic and cytogenetical effects of formaldehyde and related compounds [Review]. DNA Repair 39: 317–361. 10.1016/0165-1110(77)90011-2.
Augenreich, A; Stickford, J; Stute, N; Koontz, L; Cope, J; Bennett, C; Ratchford, SM. (2020). Vascular dysfunction and oxidative stress caused by acute formaldehyde exposure in female adults. Am J Physiol Heart Circ Physiol 319: H1369–H1379. 10.1152/ajpheart.00605.2020.33064555
Aung, W; Sakamoto, H; Sato, A; Yi, E; Thein, Z; Nwe, M; Shein, N; Linn, H; Uchiyama, S; Kunugita, N; Win-Shwe, T; Mar, O, hn. (2021). Indoor Formaldehyde Concentration, Personal Formaldehyde Exposure and Clinical Symptoms during Anatomy Dissection Sessions, University of Medicine 1, Yangon. Int J Environ Res Public Health 18. 10.3390/ijerph18020712.
Axelsson, G; Lütz, C; Rylander, R. (1984). Exposure to solvents and outcome of pregnancy in university laboratory employees. Br J Ind Med 41: 305–312.6743577
Aydemir, S; Akgun, SG; Beceren, A; Yuksel, M; Kumas, M; Erdogan, N; Sardas, S; Omurtag, GZ. (2017). Melatonin ameliorates oxidative DNA damage and protects against formaldehyde-induced oxidative stress in rats. International Journal of Clinical and Experimental Medicine 10: 6250–6261.
Aydın, S; Canpınar, H; Undeğer, U; Güç, D; Colakoğlu, M; Kars, A; Başaran, N. (2013). Assessment of immunotoxicity and genotoxicity in workers exposed to low concentrations of formaldehyde. Arch Toxicol 87: 145–153. 10.1007/s00204-012-0961-9.23100157
Aydin, S; Ogeturk, M; Kuloglu, T; Kavakli, A; Aydin, S. (2014). Effect of carnosine supplementation on apoptosis and irisin, total oxidant and antioxidants levels in the serum, liver and lung tissues in rats exposed to formaldehyde inhalation. Peptides 64C: 14–23. 10.1016/j.peptides.2014.11.008.
Babiuk, C; Steinhagen, WH; Barrow, CS. (1985). Sensory irritation response to inhaled aldehydes after formaldehyde pretreatment. Toxicol Appl Pharmacol 79: 143–149. 10.1016/0041-008x(85)90376-x.4049401
Bach, B; Pedersen, OF; Mølhave, L. (1990). Human performance during experimental formaldehyde exposure. Environ Int 16: 105–113. 10.1016/0160-4120(90)90150-5.
Bakar, E; Ulucam, E; Cerkezkayabekir, A. (2015). Protective effects of proanthocyanidin and vitamin E against toxic effects of formaldehyde in kidney tissue. Biotech Histochem 90: 69–78. 10.3109/10520295.2014.954620.25225844
Ballarin, C; Sarto, F; Giacomelli, L; Bartolucci, GB; Clonfero, E. (1992). Micronucleated cells in nasal mucosa of formaldehyde-exposed workers. Mutat Res Genet Toxicol 280: 1–7. 10.1016/0165-1218(92)90012-O.
Baluk, P; Bertrand, C; Geppetti, P; Mcdonald, DM; Nadel, JA. (1995). NK1 RECEPTORS MEDIATE LEUKOCYTE ADHESION IN NEUROGENIC INFLAMMATION IN THE RAT TRACHEA. Am J Physiol Lung Cell Mol Physiol 268: L263–L269.
Band, PR; Le, ND; Fang, R; Threlfall, WJ; Astrakianakis, G; Anderson, JT; Keefe, A; Krewski, D. (1997). Cohort mortality study of pulp and paper mill workers in British Columbia, Canada. Am J Epidemiol 146: 186–194. 10.1093/oxfordjournals.aje.a009250.9230781
Bansal, N; Uppal, V; Pathak, D. (2011). Toxic effect of formaldehyde on the respiratory organs of rabbits: a light and electron microscopic study. Toxicol Ind Health 27: 563–569. 10.1177/0748233710393398.21343228
Barbosa, E; Dos Santos, ALA; Peteffi, GP; Schneider, A; Müller, D; Rovaris, D; Bau, CHD; Linden, R; Antunes, MV; Charão, MF. (2019). Increase of global DNA methylation patterns in beauty salon workers exposed to low levels of formaldehyde. Environ Sci Pollut Res Int 26: 1304–1314. 10.1007/s11356-018-3674-7.30421373
Bardet, G; Achard, S; Loret, T; Desauziers, V; Momas, I; Seta, N. (2014). A model of human nasal epithelial cells adapted for direct and repeated exposure to airborne pollutants. Toxicol Lett 229: 144–149. 10.1016/j.toxlet.2014.05.023.24960057
Barker, S; Weinfeld, M; Murray, D. (2005). DNA-protein crosslinks: their induction, repair, and biological consequences [Review]. Mutat Res 589: 111–135. 10.1016/j.mrrev.2004.11.003.15795165
Barnes, PJ. (1992). Neurogenic inflammation and asthma [Review]. J Asthma 29: 165–180. 10.3109/02770909209099025.1351052
Barnes, PJ. (1998). Anti-inflammatory actions of glucocorticoids: molecular mechanisms. Clin Sci (Lond) 94: 557–572.9854452
Barnes, PJ; Baraniuk, JN; Belvisi, MG. (1991a). Neuropeptides in the respiratory tract. Part I [Review]. Am Rev Respir Dis 144: 1187–1198. 10.1164/ajrccm/144.5.1187.1659270
Barnes, PJ; Baraniuk, JN; Belvisi, MG. (1991b). Neuropeptides in the respiratory tract. Part II [Review]. Am Rev Respir Dis 144: 1391–1399. 10.1164/ajrccm/144.6.1391.1741554
Barrow, CS. (1983). Respiratory and metabolic response of rats and mice to formalin vapor [Letter]. Toxicology 28: 357–359. 10.1016/0300-483X(83)90009-4.6417838
Barrow, CS; Steinhagen, WH; Chang, JCF. (1983). Formaldehyde sensory irritation. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 16–25). Washington, DC: Hemisphere Publishing.
Basler, A; Wvd, H; Scheutwinkel-Reich, M. (1985). Formaldehyde-induced sister chromatid exchanges in vitro and the influence of the exogenous metabolizing systems S9 mix and primary rat hepatocytes. Arch Toxicol 58: 10–13. 10.1007/bf00292609.4074125
Bassig, BA; Zhang, L; Vermeulen, R; Tang, X; Li, G; Hu, W, ei; Guo, W; Purdue, MP; Yin, S; Rappaport, SM; Shen, M, in; Ji, Z; Qiu, C; Ge, Y; Hosgood, HD; Reiss, B; Wu, B; Xie, Y; Li, L; Yue, F, ei; Freeman, LEB; Blair, A; Hayes, RB; Huang, H; Smith, MT; Rothman, N; Lan, Q. (2016). Comparison of hematological alterations and markers of B-cell activation in workers exposed to benzene, formaldehyde and trichloroethylene. Carcinogenesis 37: 692–700. 10.1093/carcin/bgw053.27207665
Batalha, JRF; Guimaraes, ET; Lobo, DJA; Lichtenfels, AJF, C; Deur, T; Carvalho, HA; Alves, ES; Domingos, M; Rodrigues, GS; Saldiva, PHN. (1999). Exploring the clastogenic effects of air pollutants in Sao Paulo (Brazil) using the Tradescantia micronuclei assay. DNA Repair 426: 229–232.
Battelle (Battelle Columbus Laboratories). (1981). Final report on a chronic inhalation toxicology study in rats and mice exposed to formaldehyde to Chemical Industry Institute of Toxicology: Volume 1. Research Triangle Park, NC: Chemical Industry Institute of Toxicology.
Battelle (Battelle Columbus Laboratories). (1982). A chronic inhalation toxicology study in rats and mice exposed to formaldehyde. Research Triangle Park, NC: Chemical Industry Institute of Toxicology. http://al-pdf://CIIT1982 FA1340 Vol1A_OCR-2178554371/CIIT 1982 FA1340 Vol1A_OCR.pdf.
Bauchinger, M; Schmid, E. (1985). Cytogenetic effects in lymphocytes of formaldehyde workers of a paper factory. Mutat Res Genet Toxicol 158: 195–199. 10.1016/0165-1218(85)90085-0.
Bautista, DM; Jordt, SE; Nikai, T; Tsuruda, PR; Read, AJ; Poblete, J; Yamoah, EN; Basbaum, AI; Julius, D. (2006). TRPA1 Mediates the Inflammatory Actions of Environmental Irritants and Proalgesic Agents. Cell 124: 1269–1282. 10.1016/j.cell.2006.02.023.16564016
Beane Freeman, LE; Blair, A; Lubin, JH; Stewart, PA; Hayes, RB; Hoover, RN; Hauptmann, M. (2013). Mortality from solid tumors among workers in formaldehyde industries: an update of the NCI cohort. Am J Ind Med 56: 1015–1026. 10.1002/ajim.22214.23788167
Beane Freeman, LE; Blair, A; Lubin, JH; Stewart, PA; Hayes, RB; Hoover, RN; M, H. (2009). Mortality from lymphohematopoietic malignancies among workers in formaldehyde industries: The National Cancer Institute Cohort. J Natl Cancer Inst 101: 751–761. 10.1093/jnci/djp096.19436030
Beisswenger, C; Kandler, K; Hess, C; Garn, H; Felgentreff, K; Wegmann, M; Renz, H; Vogelmeier, C; Bals, R. (2006). Allergic airway inflammation inhibits pulmonary antibacterial host defense. J Immunol 177: 1833–1837. 10.4049/jimmunol.177.3.1833.16849494
Beland, FA; Fullerton, NF; Heflich, RH. (1984). Rapid isolation, hydrolysis and chromatography of formaldehyde-modified DNA. J Chromatogr A 308: 121–131. 10.1016/0378-4347(84)80202-9.
Bellavia, A; Dickerson, AS; Rotem, RS; Hansen, J; Gredal, O; Weisskopf, MG. (2021). Joint and interactive effects between health comorbidities and environmental exposures in predicting amyotrophic lateral sclerosis. Int J Hyg Environ Health 231: 113655. 10.1016/j.ijheh.2020.113655.33130429
Bellisario, V; Mengozzi, G; Grignani, E; Bugiani, M; Sapino, A; Bussolati, G; Bono, R. (2016). Towards a formalin-free hospital. Levels of 15-F2t-isoprostane and malondialdehyde to monitor exposure to formaldehyde in nurses from operating theatres. Toxicology Research 5: 1122–1129. 10.1039/c6tx00068a.30090418
Bender, JR; Mullin, LS; Grapel, GJ; Wilson, WE. (1983). Eye irritation response of humans to formaldehyde. Am Ind Hyg Assoc J 44: 463–465. 10.1080/15298668391405139.6881068
Bentayeb, M; Norback, D; Bednarek, M; Bernard, A; Cai, G; Cerrai, S; Eleftheriou, KK; Gratziou, C; Holst, GJ; Lavaud, F; Nasilowski, J; Sestini, P; Sarno, G; Sigsgaard, T; Wieslander, G; Zielinski, J; Viegi, G; Annesi-Maesano, I; Study, G. (2015). Indoor air quality, ventilation and respiratory health in elderly residents living in nursing homes in Europe. Eur Respir J 45: 1228–1238. 10.1183/09031936.00082414.25766977
Bergeron, C; Boulet, LP. (2006). Structural changes in airway diseases: characteristics, mechanisms, consequences, and pharmacologic modulation [Review]. Chest 129: 1068–1087. 10.1378/chest.129.4.1068.16608960
Berglund, B; Höglund, A; Esfandabad, HS. (2012). A bisensory method for odor and irritation detection of formaldehyde and pyridine. Chemosensory Perception 5: 146–157. 10.1007/s12078-011-9101-9.
Berglund, B; Nordin, S. (1992). Detectability and perceived intensity for formaldehyde in smokers and non-smokers. Chem Senses 17: 291–306. 10.1093/chemse/17.3.291.
Berk, JV; Hollowell, CD; Pepper, JH; Young, RA. (1980). The impact of reduced ventilation on indoor air quality in residential buildings. In Proceedings of the 73rd annual meeting of the Air Pollution Control Association. Lexington, KY: Air Pollution Control Association. https://www.osti.gov/biblio/5505445.
Berke, JH. (1987). Cytologic examination of the nasal mucosa in formaldehyde-exposed workers. J Occup Environ Med 29: 681–684.
Bermudez, E; Chen, Z; Gross, EA; Walker, CL; Recio, L; Pluta, L; Morgan, KT. (1994). Characterization of cell lines derived from formaldehyde-induced nasal tumors in rats. Mol Carcinog 9: 193–199. 10.1002/mc.2940090403.8148052
Bermudez, EG. (2004). HCHO studies - Tumor incidence [Memorandum]. Available online at (accessed
Bernardini, L; Barbosa, E; Charão, MF; Goethel, G; Muller, D; Bau, C; Steffens, NA; Stein, CS; Moresco, RN; Garcia, SC; Vencato, MS; Brucker, N. (2020). Oxidative damage, inflammation, genotoxic effect, and global DNA methylation caused by inhalation of formaldehyde and the purpose of melatonin. Toxicology Research 9: 778–789. 10.1093/toxres/tfaa079.33447362
Berrino, F; Richiardi, L; Boffetta, P; Estève, J; Belletti, I; Raymond, L; Troschel, L; Pisani, P; Zubiri, L; Ascunce, N; Gubéran, E; Tuyns, A; Terracini, B; Merletti, F; Group, MJW. (2003). Occupation and larynx and hypopharynx cancer: A job-exposure matrix approach in an international case-control study in France, Italy, Spain and Switzerland. Cancer Causes Control 14: 213–223. 10.1023/a:1023661206177.12814200
Bertazzi, PA; Pesatori, A; Guercilena, S; Consonni, D; Zocchetti, C. (1989). Cancer risk among workers producing formaldehyde-based resins: Extension of follow-up. 80: 111–122.
Bertazzi, PA; Pesatori, AC; Radice, L; Zocchetti, C. (1986). Exposure to formaldehyde and cancer mortality in a cohort of workers producing resins. Scand J Work Environ Health 12: 461–468. 10.5271/sjweh.2111.3787218
Bessac, BF; Jordt, SE. (2008). Breathtaking TRP channels: TRPA1 and TRPV1 in airway chemosensation and reflex control [Review]. Physiology (Bethesda) 23: 360–370. 10.1152/physiol.00026.2008.19074743
Bhalla, DK; Mahavni, V; Nguyen, T; Mcclure, T. (1991). Effects of acute exposure to formaldehyde on surface morphology of nasal epithelia in rats. J Toxicol Environ Health 33: 171–188. 10.1080/15287399109531516.2051493
Biagini, RE; Moorman, WJ; Knecht, EA; Clark, JC; Bernstein, IL. (1989). Acute airway narrowing in monkeys from challenge with 2.5 ppm formaldehyde generated from formalin. Arch Environ Health 44: 12–17. 10.1080/00039896.1989.9935866.2644895
Bian, RX; Han, JY; Kim, JK; Choi, IS; Lee, SG; Park, JS; Jung, YD. (2012). The effect of chronic formaldehyde exposure on the hippocampus in chronic cerebral hypoperfusion rat model. Toxicol Environ Chem 94: 1211–1224. 10.1080/02772248.2012.691505.
Bickis, M; Krewski, D. (1989). Statistical issues in the analysis of the long-term carcinogenicity bioassay in small rodents: an empirical evaluation of statistical decision rules. Toxicol Sci 12: 202–221.
Bienenstock, J; Mcdermott, MR. (2005). Bronchus- and nasal-associated lymphoid tissues [Review]. Immunol Rev 206: 22–31. 10.1111/j.0105-2896.2005.00299.x.16048540
Billionnet, C; Gay, E; Kirchner, S; Leynaert, B; Annesi-Maesano, I. (2011). Quantitative assessments of indoor air pollution and respiratory health in a population-based sample of French dwellings. Environ Res 111: 425–434. 10.1016/j.envres.2011.02.008.21397225
Binawara, BK; Ranjnee, CS; Mathur, KC; Sharma, H; Goyal, K. (2010). Acute effect of formalin on pulmonary function tests in medical students. Pak J Physiol 6: 8–10.
Binzak, BA; Vockley, JG; Jenkins, RB; Vockley, J. (2000). Structure and analysis of the human dimethylglycine dehydrogenase gene. Mol Genet Metab 69: 181–187. 10.1006/mgme.2000.2980.10767172
Blackburn, GR; Dooley, JFI; Schreiner, CA; Mackerer, C. (1991). Specific identification of formaldehyde-mediated mutagenicity using the mouse lymphoma L5178Y TK +/− assay supplemented with formaldehyde dehydrogenase. In Vitro Toxicol 4: 121–132.
Blair, A; Linos, A; Stewart, PA; Burmeister, LF; Gibson, R; Everett, G; Schuman, L; Cantor, KP. (1993). Evaluation of risks for non-Hodgkin’s lymphoma by occupation and industry exposures from a case-control study. Am J Ind Med 23: 301–312. 10.1002/ajim.4700230207.8427258
Blair, A; Stewart, P; O’Berg, M; Gaffey, W; Walrath, J; Ward, J; Bales, R; Kaplan, S; Cubit, D. (1986). Mortality among industrial workers exposed to formaldehyde. J Natl Cancer Inst 76: 1071–1084.3458945
Blair, A; Stewart, PA; Hoover, RN. (1990). Mortality from lung cancer among workers employed in formaldehyde industries. Am J Ind Med 17: 683–699. 10.1002/ajim.4700170604.2343874
Blair, A; Stewart, PA; Hoover, RN; Fraumeni, JF, Jr; Walrath, J; O’Berg, M; Gaffey, W. (1987). Cancers of the nasopharynx and oropharynx and formaldehyde exposure [Letter]. J Natl Cancer Inst 78: 191–193. 10.1093/jnci/78.1.191.3467126
Blair, A; Zheng, T; Linos, A; Stewart, PA; Zhang, YW; Cantor, KP. (2001). Occupation and leukemia: A population-based case-control study in Iowa and Minnesota. Am J Ind Med 40: 3–14. 10.1002/ajim.1066.11439392
Blasiak, J; Trzeciak, A; Malecka-Panas, E; Drzewoski, J; Wojewódzka, M. (2000). In vitro genotoxicity of ethanol and acetaldehyde in human lymphocytes and the gastrointestinal tract mucosa cells. Toxicol In Vitro 14: 287–295. 10.1016/S0887-2333(00)00022-9.10906435
Boffetta, P; Stellman, SD; Garfinkel, L. (1989). A case-control study of multiple myeloma nested in the American Cancer Society prospective study. Int J Cancer 43: 554–559. 10.1002/ijc.2910430404.2703267
Bogaert, P; Tournoy, KG; Naessens, T; Grooten, J. (2009). Where Asthma and Hypersensitivity Pneumonitis Meet and Differ Noneosinophilic Severe Asthma. Am J Pathol 174: 3–13. 10.2353/ajpath.2009.071151.19074616
Bogdanffy, MS; Morgan, PH; Starr, TB; Morgan, KT. (1987). Binding of formaldehyde to human and rat nasal mucus and bovine serum albumin. Toxicol Lett 38: 145–154. 10.1016/0378-4274(87)90122-6.3629625
Bogdanffy, MS; Plowchalk, DR; Sarangapani, R; Starr, TB; ME, A. (2001). Mode-of-action-based dosimeters for interspecies extrapolation of vinyl acetate inhalation risk [Review]. Inhal Toxicol 13: 377–396. 10.1080/08958370119592.11295869
Bogdanffy, MS; Randall, HW; Morgan, KT. (1986). Histochemical localization of aldehyde dehydrogenase in the respiratory tract of the Fischer-344 rat. Toxicol Appl Pharmacol 82: 560–567. 10.1016/0041-008X(86)90291-7.3952738
Bogdanffy, MS; Sarangapani, R; Plowchalk, DR; Jarabek, AM; Andersen, ME. (1999). A biologically based risk assessment for vinyl acetate-induced cancer and noncancer inhalation toxicity. Toxicol Sci 51: 19–35. 10.1093/toxsci/51.1.19.10496674
Boja, JW; Nielsen, JA; Foldvary, E; Truitt, EB, Jr. (1985). Acute low-level formaldehyde behavioural and neurochemical toxicity in the rat. Prog Neuropsychopharmacol Biol Psychiatry 9: 671–674. 10.1016/0278-5846(85)90038-7.4089191
Bokina, AI; Eksler, ND; Semenenko, AD; Merkur’yeva, RV. (1976). Investigation of the mechanism of action of atmospheric pollutants on the central nervous system and comparative evaluation of methods of study. Environ Health Perspect 13: 37–42. 10.2307/3428235.1269506
Bolm-Audorff, U; Vogel, C; Woitowitz, H. (1990). Occupation and smoking as risk factors of nasal and nasopharyngeal cancer. In RR Monson (Ed.), Occupational epidemiology (2nd ed., pp. 71–74). Boca Raton, FL: CRC Press.
Bonassi, S; El-Zein, R; Bolognesi, C; Fenech, M. (2011). Micronuclei frequency in peripheral blood lymphocytes and cancer risk: evidence from human studies [Review]. Mutagenesis 26: 93–100. 10.1093/mutage/geq075.21164188
Bonassi, S; Lando, C; Ceppi, M; Landi, S; Rossi, AM; Barale, R. (2004a). No association between increased levels of high-frequency sister chromatid exchange cells (HFCs) and the risk of cancer in healthy individuals. Environ Mol Mutagen 43: 134–136. 10.1002/em.20006.14991754
Bonassi, S; Norppa, H; Ceppi, M; Stromberg, U; Vermeulen, R; Znaor, A; Cebulska-Wasilewska, A; Fabianova, E; Fucic, A; Gundy, S; Hansteen, IL; Knudsen, LE; Lazutka, J; Rossner, P; Sram, RJ; Boffetta, P. (2008). Chromosomal aberration frequency in lymphocytes predicts the risk of cancer: results from a pooled cohort study of 22 358 subjects in 11 countries. Carcinogenesis 29: 1178–1183. 10.1093/carcin/bgn075.18356148
Bonassi, S; Znaor, A; Ceppi, M; Lando, C; Chang, WP; Holland, N; Kirsch-Volders, M; Zeiger, E; Ban, S; Barale, R; Bigatti, MP; Bolognesi, C; Cebulska-Wasilewska, A; Fabianova, E; Fucic, A; Hagmar, L; Joksic, G; Martelli, A; Migliore, L; Mirkova, E; Scarfi, MR; Zijno, A; Norppa, H; Fenech, M. (2007). An increased micronucleus frequency in peripheral blood lymphocytes predicts the risk of cancer in humans. Carcinogenesis 28: 625–631. 10.1093/carcin/bgl177.16973674
Bonassi, S; Znaor, A; Norppa, H; Hagmar, L. (2004b). Chromosomal aberrations and risk of cancer in humans: an epidemiologic perspective [Review]. Cytogenet Genome Res 104: 376–382. 10.1159/000077519.15162068
Boncler, M; Lukasiak, M; Dastych, J; Golanski, J; Watala, C. (2019). Differentiated mitochondrial function in mouse 3T3 fibroblasts and human epithelial or endothelial cells in response to chemical exposure. Basic & Clinical Pharmacology & Toxicology Online Pharmacology Online 124: 199–210. 10.1111/bcpt.13117.
Bond, GG; Flores, GH; Shellenberger, RJ; Cartmill, JB; Fishbeck, WA; Cook, RR. (1986). Nested case-control study of lung cancer among chemical workers. Am J Epidemiol 124: 53–66.3717140
Bono, R; Munnia, A; Romanazzi, V; Bellisario, V; Cellai, F; Peluso, MEM. (2016). Formaldehyde-induced toxicity in the nasal epithelia of workers of a plastic laminate plant. Toxicology Research 5: 752–760. 10.1039/c5tx00478k.30090386
Bono, R; Romanazzi, V; Munnia, A; Piro, S; Allione, A; Ricceri, F; Guarrera, S; Pignata, C; Matullo, G; Wang, P; Giese, RW; Peluso, M. (2010). Malondialdehyde-deoxyguanosine adduct formation in workers of pathology wards: the role of air formaldehyde exposure. Chem Res Toxicol 23: 1342–1348. 10.1021/tx100083x.20707408
Bono, R; Romanazzi, V; Pirro, V; Degan, R; Pignata, C; Suppo, E; Pazzi, M; Vincenti, M. (2012). Formaldehyde and tobacco smoke as alkylating agents: The formation of N-methylenvaline in pathologists and in plastic laminate workers. Sci Total Environ 414: 701–707. 10.1016/j.scitotenv.2011.10.047.22104379
Bono, R; Vincenti, M; Schiliro’, T; Scursatone, E; Pignata, C; Gilli, G. (2006). N-Methylenvaline in a group of subjects occupationally exposed to formaldehyde. Toxicol Lett 161: 10–17. 10.1016/j.toxlet.2005.07.016.16153790
Boreiko, CJ; Ragan, DL. (1983). Formaldehyde effects in the C3H/10T½ cell transformation assay. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 63–71). Washington, DC: Hemisphere Publishing Corporation.
Bos, PMJ; Busschers, M; Arts, JHE. (2002). Evaluation of the sensory irritation test (Alarie test) for the assessment of respiratory tract irritation. J Occup Environ Med 44: 968–976. 10.1097/01.jom.0000034342.94005.cc.12391777
Bosworth, D; Crofton-Sleigh, C; Venitt, S. (1987). A forward mutation assay using ampicillin-resistance in Escherichia coli designed for investigating the mutagenicity of biological samples. Mutagenesis 2: 455–467.3127657
Bouraoui, S; Mougou, S; Brahem, A; Tabka, F; Ben Khelifa, H; Harrabi, I; Mrizek, N; Elghezal, H; Saad, A. (2013). A combination of micronucleus assay and fluorescence in situ hybridization analysis to evaluate the genotoxicity of formaldehyde. Arch Environ Contam Toxicol 64: 337–344. 10.1007/s00244-012-9828-6.23132144
Boysen, M; Solberg, LA. (1982). Changes in the nasal mucosa of furniture workers. A pilot study. Scand J Work Environ Health 8: 273–282. 10.5271/sjweh.2466.7170624
Boysen, M; Zadig, E; Digernes, V; Abeler, V; Reith, A. (1990). Nasal mucosa in workers exposed to formaldehyde: a pilot study. Occup Environ Med 47: 116–121. 10.1136/oem.47.2.116.
Bracken, MJ; Leasa, DJ; Morgan, WKC. (1985). Exposure to formaldehyde: Relationship to respiratory symptoms and function. Can J Public Health 76: 312–316.4084884
Branco, P; Alvim-Ferraz, M; Martins, FG; Sousa, S. (2019). Quantifying indoor air quality determinants in urban and rural nursery and primary schools. Environ Res 176: 108534. 10.1016/j.envres.2019.108534.31220738
Branco, PT; Nunes, RA; Alvim-Ferraz, MC; Martins, FG; Sousa, SI. (2015). Children’s exposure to indoor air in urban nurseries - Part II: Gaseous pollutants’ assessment. Environ Res 142: 662–670. 10.1016/j.envres.2015.08.026.26342590
Branco, PTB; Alvim-Ferraz, MCM; Martins, FG; Ferraz, C; Vaz, LG; Sousa, SIV. (2020a). Impact of indoor air pollution in nursery and primary schools on childhood asthma. Sci Total Environ 745: 140982. 10.1016/j.scitotenv.2020.140982.32736106
Branco, PTB; Alvim-Ferraz, MCM; Martins, FG; Ferraz, C; Vaz, LG; Sousa, SIV. (2020b). Impact of indoor air pollution in nursery and primary schools on childhood asthma: Supplemental Data [Supplemental Data]. Sci Total Environ 745.
Brand, G; Jacquot, L. (2002). Sensitization and desensitization to allyl isothiocyanate (mustard oil) in the nasal cavity. Chem Senses 27: 593–598.12200338
Breysse, PA. (1984). Formaldehyde levels and accompanying symptoms associated with individuals residing in over 1000 conventional and mobile homes in the state of Washington. In B Berglund; T Lindvall; J Sundell (Eds.), Indoor air: Proceedings of the 3rd International Conference on Indoor Air Quality and Climate Volume 3: Sensory and hyperreactivity reactions to sick buildings (pp. 403–408). Stockholm, Sweden: Swedish Council for Building Research. https://search.proquest.com/docview/14197938?accountid=171501.
Brinton, LA; Blot, WJ; Becker, JA; Winn, DM; Browder, JP; Farmer, JC, Jr; Fraumeni, JF, Jr. (1984). A case-control study of cancers of the nasal cavity and paranasal sinuses. Am J Epidemiol 119: 896–906. 10.1093/oxfordjournals.aje.a113812.6731431
Brinton, LA; Blot, WJ; Fraumeni, JF, Jr. (1985). Nasal cancer in the textile and clothing industries. Occup Environ Med 42: 469–474.
Broder, I; Corey, P; Brasher, P; Lipa, M; Cole, P. (1988a). Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam: III. Health and house variables following remedial work. Environ Res 45: 179–203. 10.1016/S0013-9351(88)80046-X.3349974
Broder, I; Corey, P; Cole, P; Lipa, M; Mintz, S; Nethercott, JR. (1988b). Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam: I Methodology. Environ Res 45: 141–155. 10.1016/S0013-9351(88)80044-6.3349973
Broder, I; Corey, P; Cole, P; Lipa, M; Mintz, S; Nethercott, JR. (1988c). Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam: II initial health and house variables and exposure-response relationships. Environ Res 45: 156–178. 10.1016/S0013-9351(88)80045-8.3127198
Brondeau, MT; Bonnet, P; Guenier, JP; Simon, P; de Ceaurriz, J. (1990). Adrenal-dependent leucopenia after short-term exposure to various airborne irritants in rats. J Appl Toxicol 10: 83–86. 10.1002/jat.2550100204.2362083
Bruno, E; Somma, G; Russo, C; Porozaj, D; Pietroiusti, A; Alessandrini, M; Magrini, A. (2018). Nasal cytology as a screening tool in formaldehyde-exposed workers. Occup Med (Lond) 68: 307–313. 10.1093/occmed/kqy052.29668989
Brusick, DJ. (1983). Genetic and transforming activity of formaldehyde. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 72–84). Washington, DC: Hemisphere Publishing.
Buckley, LA; Jiang, XZ; James, RA; Morgan, KT; Barrow, CS. (1984). Respiratory tract lesions induced by sensory irritants at the RD50 concentration. Toxicol Appl Pharmacol 74: 417–429. 10.1016/0041-008X(84)90295-3.6740688
Buckton, KE; Evans, HJ. (1973). Methods for the Analysis of Human Chromosome Aberrations. Geneva: WHO.
Bull, RJ. (2000). Mode of action of liver tumor induction by trichloroethylene and its metabolites, trichloroacetate and dichloroacetate [Review]. Environ Health Perspect 108: 241–259. 10.1289/ehp.00108s2241.10807555
Burgaz, S; Cakmak, G; Erdem, O; Yilmaz, M; Karakaya, AE. (2001). Micronuclei frequencies in exfoliated nasal mucosa cells from pathology and anatomy laboratory workers exposed to formaldehyde. Neoplasma 48: 144–147.11478696
Burgaz, S; Erdem, O; Cakmak, G; Erdem, N; Karakaya, A; Karakaya, AE. (2002). Cytogenetic analysis of buccal cells from shoe-workers and pathology and anatomy laboratory workers exposed to n-hexane, toluene, methyl ethyl ketone and formaldehyde. Biomarkers 7: 151–161. 10.1080/13547500110113242.12101634
Burgos-Barragan, G; Wit, N; Meiser, J; Dingler, FA; Pietzke, M; Mulderrig, L; Pontel, LB; Rosado, IV; Brewer, TF; Cordell, RL; Monks, PS; Chang, CJ; Vazquez, A; Patel, KJ. (2017). Mammals divert endogenous genotoxic formaldehyde into one-carbon metabolism. Nature 548: 549–554. 10.1038/nature23481.28813411
Burns-Naas, LA; Hastings, KL; Ladics, GS; Makris, SL; Parker, GA; Holsapple, MP. (2008). What’s so special about the developing immune system? [Review]. Int J Toxicol 27: 223–254. 10.1080/10915810801978110.18404545
Callas, PW; Pastides, H; Hosmer, DW. (1998). Empirical comparisons of proportional hazards, poisson, and logistic regression modeling of occupational cohort data. Am J Ind Med 33: 33–47. 10.1002/(sici)1097-0274(199801)33:1<33::aid-ajim5>3.0.co;2-x.9408527
Campbell Jr, JL; Gentry, PR; Clewell III, HJ; Andersen, ME. (2020). A kinetic analysis of DNA-deoxy guanine adducts in the nasal epithelium produced by inhaled formaldehyde in rats-assessing contributions to adduct production from both endogenous and exogenous sources of formaldehyde. Toxicol Sci 177: 325–333. 10.1093/toxsci/kfaa122.32735340
Cao, FH; Cai, J; Liu, ZM; Li, H; You, HH; Mei, YF; Yang, X; Ding, SM. (2015). [Toxic effect of formaldehyde on mouse different brain regions]. Sheng Li Xue Bao 67: 497–504.26490067
Cap, P; Dryahina, K; Pehal, F; Spanel, P. (2008). Selected ion flow tube mass spectrometry of exhaled breath condensate headspace. Rapid Commun Mass Spectrom 22: 2844–2850. 10.1002/rcm.3685.18712707
Caria, H; Chaveca, T; Laires, A; Rueff, J. (1995). Genotoxicity of quercetin in the micronucleus assay in mouse bone marrow erythrocytes, human lymphocytes, V79 cell line and identification of kinetochore-containing (CREST staining) micronuclei in human lymphocytes. Mutat Res 343: 85–94.7791812
Carr, MJ; Undem, BJ. (2001). Inflammation-induced plasticity of the afferent innervation of the airways. Environ Health Perspect 4: 567–571.
Casanova-Schmitz, M; David, RM; Heck, H. (1984a). Oxidation of formaldehyde and acetaldehyde by NAD+-dependent dehydrogenases in rat nasal mucosal homogenates. Biochem Pharmacol 33: 1137–1142. 10.1016/0006-2952(84)90526-4.6477684
Casanova-Schmitz, M; Heck, H. (1983). Effects of formaldehyde exposure on the extractability of DNA from proteins in the rat nasal mucosa. Toxicol Appl Pharmacol 70: 121–132. 10.1016/0041-008x(83)90185-0.6193611
Casanova-Schmitz, M; Starr, TB; Heck, HD. (1984b). Differentiation between metabolic incorporation and covalent binding in the labeling of macromolecules in the rat nasal mucosa and bone marrow by inhaled [14C]- and [3H]formaldehyde. Toxicol Appl Pharmacol 76: 26–44. 10.1016/0041-008x(84)90026-7.6207627
Casanova, M; Bell, DA; Heck, H. (1997). Dichloromethane metabolism to formaldehyde and reaction of formaldehyde with nucleic acids in hepatocytes of rodents and humans with and without glutathione S-transferase T1 and M1 genes. Fundam Appl Toxicol 37: 168–180. 10.1093/toxsci/37.2.168.9242590
Casanova, M; Deyo, DF; Heck, H. (1989). Covalent binding of inhaled formaldehyde to DNA in the nasal mucosa of Fischer 344 rats: Analysis of formaldehyde and DNA by high-performance liquid chromatography and provisional pharmacokinetic interpretation. Fundam Appl Toxicol 12: 397–417. 10.1016/0272-0590(89)90015-8.2731656
Casanova, M; Heck, H. (1987). Further studies of the metabolic incorporation and covalent binding of inhaled [3H]- and [14C]formaldehyde in Fischer-344 rats: Effects of glutathione depletion. Toxicol Appl Pharmacol 89: 105–121. 10.1016/0041-008X(87)90181-5.2438809
Casanova, M; Heck, H. (1997). Lack of evidence for the involvement of formaldehyde in the hepatocarcinogenicity of methyl tertiary-butyl ether in CD-1 mice. Chem Biol Interact 105: 131–143.9251725
Casanova, M; Heck, H; Everitt, JI; Harrington, WW, Jr; Popp, JA. (1988). Formaldehyde concentrations in the blood of rhesus monkeys after inhalation exposure. Food Chem Toxicol 26: 715–716. 10.1016/0278-6915(88)90071-3.3198038
Casanova, M; Morgan, KT; Gross, EA; Moss, OR; Heck, H. (1994). DNA-protein cross-links and cell replication at specific sites in the nose of F344 rats exposed subchronically to formaldehyde. Fundam Appl Toxicol 23: 525–536. 10.1006/faat.1994.1137.7867904
Casanova, M; Morgan, KT; Steinhagen, WH; Everitt, JI; Popp, JA; Heck, H. (1991). Covalent binding of inhaled formaldehyde to DNA in the respiratory tract of rhesus monkeys: pharmacokinetics, rat-to-monkey interspecies scaling, and extrapolation to man. Toxicol Sci 17: 409–428. 10.1016/0272-0590(91)90230-2.
Casanovaschmitz, M; Starr, TB; Heck, HD. (1984). DIFFERENTIATION BETWEEN METABOLIC INCORPORATION AND COVALENT BINDING IN THE LABELING OF MACROMOLECULES IN THE RAT NASAL-MUCOSA AND BONE-MARROW BY INHALED [C-14] FORMALDEHYDE AND [H-3] FORMALDEHYDE. Toxicol Appl Pharmacol 76: 26–44. 10.1016/0041-008X(84)90026-7.6207627
Cassee, FR; Arts, JHE; Groten, JP; Feron, VJ. (1996a). Sensory irritation to mixtures of formaldehyde, acrolein, and acetaldehyde in rats. Arch Toxicol 70: 329–337. 10.1007/s002040050282.8975631
Cassee, FR; Feron, VJ. (1994). Biochemical and histopathological changes in nasal epithelium of rats after 3-day intermittent exposure to formaldehyde and ozone alone or in combination. Toxicol Lett 72: 257–268. 10.1016/0378-4274(94)90037-x.7911263
Cassee, FR; Groten, JP; Feron, VJ. (1996b). Changes in the nasal epithelium of rats exposed by inhalation to mixtures of formaldehyde, acetaldehyde, and acrolein. Toxicol Sci 29: 208–218. 10.1006/faat.1996.0024.
Casset, A; Marchand, C; Purohit, A; le Calve, S; Uring-Lambert, B; Donnay, C; Meyer, P; de Blay, F. (2006). Inhaled formaldehyde exposure: effect on bronchial response to mite allergen in sensitized asthma patients. Allergy 61: 1344–1350. 10.1111/j.1398-9995.2006.01174.x.17002712
Casset, A; Purohit, A; Marchand, C; Le Calve, S; Pauli, G; de Blay, F. (2007). Inhaled formaldehyde and the bronchial response. Rev Fr Allergol Immunol Clin 47: 80–83. 10.1016/j.allerg.2006.10.009.
CDC (Centers for Disease Control and Prevention). (2011). Formaldehyde exposures during Brazilian blowout hair smoothing treatment at a hair salon - Ohio. (HETA-2011-0014-3147). Atlanta, GA: Department of Health and Human Services, CDC. 10.26616/NIOSHHETA201100143147.
Ceder, R; Merne, M; Staab, C; al., e. (2007a). The application of normal, SV40 T-antigen-immortalized and tumour-derived oral keratinocytes, under serum-free conditions, to the study of the probability of cancer progression as a result of environmental exposure to chemicals. Altern Lab Anim 35: 621–639.18186669
Ceder, R; Merne, M; Staab, CA; Nilsson, JA; Höög, JO; Dressler, D; Engelhart, K; Grafström, RC. (2007b). The application of normal, SV40 T-antigen-immortalised and tumour-derived oral keratinocytes, under serum-free conditions, to the study of the probability of cancer progression as a result of environmental exposure to chemicals. Altern Lab Anim 35: 621–639. 10.1177/026119290703500603.18186669
Cederbaum, AI; Qureshi, A. (1982). Role of catalase and hydroxyl radicals in the oxidation of methanol by rat liver microsomes. Biochem Pharmacol 31: 329–335. 10.1016/0006-2952(82)90179-4.6280725
Chanet, R; Izard, C; Moustacchi, E. (1975). Genetic effects of formaldehyde in yeast. I. Influence of the growth stages on killing and recombination. Mutat Res 33: 179–186. 10.1016/0027-5107(75)90193-1.765800
Chang, JCF; Barrow, CS. (1984). Sensory irritation tolerance and cross-tolerance in F-344 rats exposed to chlorine or formaldehyde gas. Toxicol Appl Pharmacol 76: 319–327. 10.1016/0041-008X(84)90013-9.6495337
Chang, JCF; Gross, EA; Swenberg, JA; Barrow, CS. (1983). Nasal cavity deposition, histopathology, and cell proliferation after single or repeated formaldehyde exposures in B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 68: 161–176. 10.1016/0041-008x(83)90001-7.6857658
Chang, JCF; Steinhagen, WH; Barrow, CS. (1981). Effect of single or repeated formaldehyde exposure on minute volume of B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 61: 451–459. 10.1016/0041-008x(81)90368-9.7330883
Chang, M; Park, H; Ha, M; Hong, YC; Lim, YH; Kim, Y; Kim, YJ; Lee, D; Ha, EH. (2017). The effect of prenatal TVOC exposure on birth and infantile weight: the Mothers and Children’s Environmental Health study. Pediatr Res 82: 423–428. 10.1038/pr.2017.55.28422943
Chaw, YF; Crane, LE; Lange, P; Shapiro, R. (1980). Isolation and identification of cross-links from formaldehyde-treated nucleic acids. Biochemistry 19: 5525–5531.7459328
Checkoway, H; Dell, LD; Boffetta, P; Gallagher, AE; Crawford, L; Lees, PS; Mundt, KA. (2015). Formaldehyde Exposure and Mortality Risks From Acute Myeloid Leukemia and Other Lymphohematopoietic Malignancies in the US National Cancer Institute Cohort Study of Workers in Formaldehyde Industries. J Occup Environ Med 57: 785–794. 10.1097/JOM.0000000000000466.26147546
Checkoway, H; Ray, RM; Lundin, JI; Astrakianakis, G; Seixas, NS; Camp, JE; Wernli, KJ; Fitzgibbons, ED; Li, W; Feng, Z; Gao, DL; Thomas, DB. (2011). Lung cancer and occupational exposures other than cotton dust and endotoxin among women textile workers in Shanghai, China. Occup Environ Med 68: 425–429. 10.1136/oem.2010.059519.21131604
Chen, D; Fang, L; Mei, S; Li, H; Xu, X; Des Marais, TL; Lu, K; Liu, XS; Jin, C. (2017). Regulation of Chromatin Assembly and Cell Transformation by Formaldehyde Exposure in Human Cells. Environ Health Perspect 125: 097019. 10.1289/EHP1275.28937961
Cheng, G; Shi, Y; Sturla, SJ; Jalas, J. R.; Mcintee, EJ; Villalta, PW; Wang, M; Hecht, SS. (2003). Reactions of formaldehyde plus acetaldehyde with deoxyguanosine and DNA: formation of cyclic deoxyguanosine adducts and formaldehyde cross-links. Chem Res Toxicol 16: 145–152. 10.1021/tx025614r.12588185
Cheng, G; Wang, M; Upadhyaya, P; Villalta, PW; Hecht, SS. (2008). Formation of formaldehyde adducts in the reactions of DNA and deoxyribonucleosides with alpha-acetates of 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone (NNK), 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol (NNAL), and N-nitrosodimethylamine (NDMA). Chem Res Toxicol 21: 746–751. 10.1021/tx7003823.18205321
Cheng, J; Zhang, L; Tang, Y; Li, Z. (2016). The toxicity of continuous long-term low-dose formaldehyde inhalation in mice. Immunopharmacol Immunotoxicol 38: 495–501. 10.1080/08923973.2016.1248844.27819568
Cheng, YJ; Hildesheim, A; Hsu, MM; Chen, IH; Brinton, LA; Levine, PH; Chen, CJ; Yang, CS. (1999). Cigarette smoking, alcohol consumption and risk of nasopharyngeal carcinoma in Taiwan. Cancer Causes Control 10: 201–207. 10.1023/A:1008893109257.10454065
Cheng, YS; Hansen, GK; Su, YF; Yeh, HC; Morgan, KT. (1990). Deposition of ultrafine aerosols in rat nasal molds. Toxicol Appl Pharmacol 106: 222–233.2256113
Cheng, Z; Li, Y; Liang, B; Wang, C. (2004). [Investigation of formaldehyde level and health of personnel in clinical pathology]. 29: 266–267.
Cheung C, WS; Beech, IB; Campbell, SA; Satherley, J; Schiffrin, DJ. (1994). The effect of industrial biocides on sulphate-reducing bacteria under high pressure. Int Biodeterior Biodegradation 33: 299–310.
Chia, SE; Ong, CN; Foo, SC; Lee, HP. (1992). Medical students’ exposure to formaldehyde in a gross anatomy dissection laboratory. J Am Coll Health 41: 115–119. 10.1080/07448481.1992.9936310.1430673
Chiazze, L, Jr; Watkins, DK; Fryar, C. (1997). Historical cohort mortality study of a continuous filament fiberglass manufacturing plant. I. White men. J Occup Environ Med 39: 432–441. 10.1097/00043764-199705000-00009.9172088
Choi, DW; Moon, KW; Byeon, SH; Lee, EI; Sul, DG; Lee, JH; Oh, EH; Kim, YH. (2009). Indoor volatile organic compounds in atopy patients’ houses in South Korea. Indoor Built Environ 18: 144–154. 10.1177/1420326X08101945.
Chonglei, L; Fan, W; Wei, L; Yihe, J. (2012). Effects of Exposure to VOCs on Spatial Learning and Memory Capacity and the Expression of NMDA Receptor in Mice. Journal of Animal and Veterinary Advances 11: 3355–3364.
Ciftci, G; Aksoy, A; Cenesiz, S; Sogut, MU; Yarim, GF; Nisbet, C; Guvenc, D; Ertekin, A. (2015). Therapeutic role of curcumin in oxidative DNA damage caused by formaldehyde. Microsc Res Tech 78: 391–395. 10.1002/jemt.22485.25761397
CIIT (Chemical Industry Institute of Toxicology). (1999). Formaldehyde: Hazard characterization and dose-response assessment for carcinogenicity by the route of inhalation (revised edition). Research Triangle Park, NC.
Clement, PA; Stoop, AP; Kaufman, L. (1987). The influence of formaldehyde on the nasal mucosa. Rhinology 25: 29–34.3576059
Coggon, D; Harris, EC; Poole, J; Palmer, KT. (2003). Extended follow-up of a cohort of British chemical workers exposed to formaldehyde. J Natl Cancer Inst 95: 1608–1615. 10.1093/jnci/djg046.14600093
Coggon, D; Ntani, G; Harris, EC; Palmer, KT. (2014). Upper Airway Cancer, Myeloid Leukemia, and Other Cancers in a Cohort of British Chemical Workers Exposed to Formaldehyde. Am J Epidemiol 179: 1301–1311. 10.1093/aje/kwu049.24714728
Cohen Hubal, EA; Schlosser, PM; Conolly, RB; Kimbell, JS. (1997). Comparison of inhaled formaldehyde dosimetry predictions with DNA-protein cross-link measurements in the rat nasal passages. Toxicol Appl Pharmacol 143: 47–55. 10.1006/taap.1996.8076.9073591
Cohn, L; Elias, JA; Chupp, GL. (2004). Asthma: mechanisms of disease persistence and progression [Review]. Annu Rev Immunol 22: 789–815. 10.1146/annurev.immunol.22.012703.104716.15032597
Comba, P; Barbieri, PG; Battista, G; Belli, S; Ponterio, F; Zanetti, D; Axelson, O. (1992a). Cancer of the nose and paranasal sinuses in the metal industry: a case-control study. Occup Environ Med 49: 193–196. 10.1136/oem.49.3.193.
Comba, P; Battista, G; Belli, S; Decapua, B; Merler, E; Orsi, D; Rodella, S; Vidigni, C; Axelson, O. (1992b). A case-control study of cancer of the nose and paranasal sinuses and occupational exposures. Am J Ind Med 22: 511–520. 10.1002/ajim.4700220406.1442786
Cometto-Muñiz, JE; Hernández, SM. (1990). Odorous and pungent attributes of mixed and unmixed odorants. Percept Psychophys 47: 391–399. 10.3758/bf03210879.2345692
Conaway, CC; Whysner, J; Verna, LK; Williams, GM. (1996). Formaldehyde mechanistic data and risk assessment: Endogenous protection from DNA adduct formation [Review]. Pharmacol Ther 71: 29–55. 10.1016/0163-7258(96)00061-7.8910948
Connor, TH; Barrie, MD; Theiss, JC; Matney, TS; Ward, JB. (1983). Mutagenicity of formalin in the Ames assay. Mutat Res Lett 119: 145–149. 10.1016/0165-7992(83)90122-7.
Connor, TH; Theiss, JC; Hanna, HA; Monteith, DK; Matney, TS. (1985a). Genotoxicity of organic chemicals frequently found in the air of mobile homes. Toxicol Lett 25: 33–40. 10.1016/0378-4274(85)90097-9.3887653
Connor, TH; Ward, JB; Legator, MS. (1985b). Absence of mutagenicity in the urine of autopsy service workers exposed to formaldehyde: Factors influencing mutagenicity testing of urine. Int Arch Occup Environ Health 56: 225–237. 10.1007/BF00396600.4066051
Conolly, RB. (2002). The use of biologically based modeling in risk assessment [Review]. Toxicology 181–182: 275–279. 10.1016/S0300-483X(02)00295-0.
Conolly, RB; Kimbell, JS; Janszen, D; Schlosser, PM; Kalisak, D; Preston, J; Miller, FJ. (2003). Biologically motivated computational modeling of formaldehyde carcinogenicity in the F344 rat. Toxicol Sci 75: 432–447. 10.1093/toxsci/kfg182.12857938
Conolly, RB; Kimbell, JS; Janszen, D; Schlosser, PM; Kalisak, D; Preston, J; Miller, FJ. (2004). Human respiratory tract cancer risks of inhaled formaldehyde: dose-response predictions derived from biologically-motivated computational modeling of a combined rodent and human dataset. Toxicol Sci 82: 279–296. 10.1093/toxsci/kfh223.15254341
Conolly, RB; Lilly, PD; Kimbell, JS. (2000). Simulation modelling of the tissue disposition of formaldehyde to predict nasal DNA-protein cross-links in Fischer 344 rats, rhesus monkeys, and humans. Environ Health Perspect 108: 919–924. 10.2307/3454325.
Conolly, RB; Lutz, WK. (2004). Nonmonotonic dose-response relationships: Mechanistic basis, kinetic modeling, and implications for risk assessment. Toxicol Sci 77: 151–157. 10.1093/toxsci/kfh007.14600281
Conolly, RB; Miller, FJ; Kimbell, JS; Janszen, D. (2009). Letter to the editor: Formaldehyde risk assessment [Letter]. Ann Occup Hyg 53: 181–184. 10.1093/annhyg/men084.19174485
Coombs, KC; Chew, GL; Schaffer, C; Ryan, PH; Brokamp, C; Grinshpun, SA; Adamkiewicz, G; Chillrud, S; Hedman, C; Colton, M; Ross, J; Reponen, T. (2016). Indoor air quality in green-renovated vs. non-green low-income homes of children living in a temperate region of US (Ohio). Sci Total Environ 554: 178–185. 10.1016/j.scitotenv.2016.02.136.26950631
Coon, RA; Jones, RA; Jenkins, LJ, Jr; Siegel, J. (1970). Animal inhalation studies on ammonia, ethylene glycol, formaldehyde, dimethylamine, and ethanol. Toxicol Appl Pharmacol 16: 646–655. 10.1016/0041-008X(70)90069-4.4987187
Corley, RA; Kabilan, S; Kuprat, AP; Carson, JP; Jacob, RE; Minard, KR; Teeguarden, JG; Timchalk, C; Pipavath, S; Glenny, R; Einstein, DR. (2015). Comparative risks of aldehyde constituents in cigarette smoke using transient computational fluid dynamics/physiologically based pharmacokinetic models of the rat and human respiratory tracts. Toxicol Sci 146: 65–88. 10.1093/toxsci/kfv071.25858911
Cosma, GN; Marchok, AC. (1988). Benzo[a]pyrene- and formaldehyde-induced DNA damage and repair in rat tracheal epithelial cells. Toxicology 51: 309–320. 10.1016/0300-483X(88)90159-X.3176033
Cosma, GN; Wilhite, AS; Marchok, AC. (1988). The detection of DNA-protein cross-links in rat tracheal implants exposed in vivo to benzo[a]pyrene and formaldehyde. Cancer Lett 42: 13–21. 10.1016/0304-3835(88)90233-9.3180031
Costa, M; Zhitkovich, A; Harris, M; Paustenbach, D; Gargas, M. (1997). DNA-protein cross-links produced by various chemicals in cultured human lymphoma cells. J Toxicol Environ Health 50: 433–449. 10.1080/00984109708984000.9140463
Costa, S; Carvalho, S; Costa, C; Coelho, P; Silva, S; Santos, LS; Gaspar, JF; Porto, B; Laffon, B; Teixeira, JP. (2015). Increased levels of chromosomal aberrations and DNA damage in a group of workers exposed to formaldehyde. Mutagenesis 30: 463–473. 10.1093/mutage/gev002.25711496
Costa, S; Coelho, P; Costa, C; Silva, S; Mayan, O; Santos, LS; Gaspar, J; Teixeira, JP. (2008). Genotoxic damage in pathology anatomy laboratory workers exposed to formaldehyde. Toxicology 252: 40–48. 10.1016/j.tox.2008.07.056.18721846
Costa, S; Costa, C; Madureira, J; Valdiglesias, V; Teixeira-Gomes, A; Guedes de Pinho, P; Laffon, B; Teixeira, JP. (2019). Occupational exposure to formaldehyde and early biomarkers of cancer risk, immunotoxicity and susceptibility. Environ Res 179: 108740. 10.1016/j.envres.2019.108740.31563789
Costa, S; García-Lestón, J; Coelho, M; Coelho, P; Costa, C; Silva, S; Porto, B; Laffon, B; Teixeira, JP. (2013). Cytogenetic and immunological effects associated with occupational formaldehyde exposure. J Toxicol Environ Health A 76: 217–229. 10.1080/15287394.2013.757212.23514064
Costa, S; Pina, C; Coelho, P; Costa, C; Silva, S; Porto, B; Laffon, B; Teixeira, JP. (2011). Occupational exposure to formaldehyde: genotoxic risk evaluation by comet assay and micronucleus test using human peripheral lymphocytes. J Toxicol Environ Health A 74: 1040–1051. 10.1080/15287394.2011.582293.21707428
Coste, A; Rateau, JG; Roudot-Thoraval, F; Chapelin, C; Gilain, L; Poron, F; Peynegre, R; Bernaudin, JF; Escudier, E. (1996). Increased epithelial cell proliferation in nasal polyps. Arch Otolaryngol Head Neck Surg 122: 432–436. 10.1001/archotol.1996.01890160072013.8600930
Cox, DR; Hinkley, DV. (1974). Theoretical statistics. London, UK: Chapman and Hall.
Cox, DR; Oakes, D. (1984). Analysis of survival data. London, UK: Chapman and Hall.
Craft, TR; Bermudez, E; Skopek, TR. (1987). Formaldehyde mutagenesis and formation of DNA-protein crosslinks in human lymphoblasts in vitro. Mutat Res 176: 147–155. 10.1016/0027-5107(87)90262-4.3796657
Crosby, RM; Richardson, KK; Craft, TR; Benforado, KB; Liber, HL; Skopek, TR. (1988). Molecular analysis of formaldehyde-induced mutations in human lymphoblasts and E. coli. Environ Mol Mutagen 12: 155–166. 10.1002/em.2860120202.2900762
Crouch, EA. (1989). TOX-RISK: a program for fitting dose-response formulae and extrapolating between species. Risk Anal 9: 599–603. 10.1111/j.1539-6924.1989.tb01270.x.2608950
Crump, K. (2002). Benchmark analysis. In A El-Shaarawi; WW Piegorsch (Eds.), Encyclopedia of environmetrics (pp. 163–170). West Sussex, UK: John Wiley & Sons Ltd. 10.1002/9780470057339.vab009.
Crump, KS. (1994a). Limitations of biological models of carcinogenesis for low-dose extrapolation. Risk Anal 14: 883–886. 10.1111/j.1539-6924.1994.tb00050.x.7846321
Crump, KS. (1994b). Use of mechanistic models to estimate low-dose cancer risks. Risk Anal 14: 1033–1038.7846310
Crump, KS; Bussard, DA; Chen, C; Jinot, J; Subramaniam, R. (2014). The bottom-up approach does not necessarily bound low-dose risk [Letter]. Regul Toxicol Pharmacol 70: 735–736. 10.1016/j.yrtph.2014.10.008.25455229
Crump, KS; Chen, C; Chiu, WA; Louis, TA; Portier, CJ; Subramaniam, RP; White, PD. (2010). What role for biologically based dose-response models in estimating low-dose risk? [Review]. Environ Health Perspect 118: 585–588. 10.1289/ehp.0901249.20056564
Crump, KS; Chen, C; Fox, JF; Subramaniam, R. (2009). Reply to Conolly et al [Letter]. Ann Occup Hyg 53: 184–189. 10.1093/annhyg/men088.
Crump, KS; Chen, C; Fox, JF; Van Landingham, C; Sumbramaniam, R. (2008). Sensitivity analysis of biologically motivated model for formaldehyde-induced respiratory cancer in humans. Ann Occup Hyg 52: 481–495. 10.1093/annhyg/men038.18628253
Crump, KS; Hoel, DG; Langley, CH; Peto, R. (1976). Fundamental carcinogenic processes and their implications for low dose risk assessment. Cancer Res 36: 2973–2979.975067
Crump, KS; Subramaniam, RP; Van Landingham, CB. (2005). A numerical solution to the nonhomogeneous two-stage MVK model of cancer. Risk Anal 25: 921–926. 10.1111/j.1539-6924.2005.00651.x.16268939
Cui, Y; Li, H; Wu, S; Zhao, R; Du, D; Ding, Y; Nie, H; Ji, HL. (2016). Formaldehyde impairs transepithelial sodium transport. Sci Rep 6: 35857. 10.1038/srep35857.27762337
D’Errico, A; Pasian, S; Baratti, A; Zanelli, R; Alfonzo, S; Gilardi, L; Beatrice, F; Bena, A; Costa, G. (2009). A case-control study on occupational risk factors for sino-nasal cancer. Occup Environ Med 66: 448–455. 10.1136/oem.2008.041277.19153109
da Silva, CM; Leal, MP; Brochetti, RA; Braga, T; Vitoretti, LB; Saraiva Camara, NO; Damazo, AS; Ligeiro-De-Oliveira, A; Chavantes, MC; Lino-Dos-Santos-Franco, A. (2015). Low Level Laser Therapy Reduces the Development of Lung Inflammation Induced by Formaldehyde Exposure. PLoS ONE 10: e0142816. 10.1371/journal.pone.0142816.26569396
Dalbey, WE. (1982). Formaldehyde and tumors in hamster respiratory tract. Toxicology 24: 9–14. 10.1016/0300-483X(82)90058-0.7135407
Dallas, CE; Badeaux, P; Theiss, JC; Fairchild, EJ. (1989). The influence of inhaled formaldehyde on rat lung cytochrome P450. Environ Res 49: 50–59. 10.1016/S0013-9351(89)80021-0.2721477
Dallas, CE; Mellard, DN; Theiss, JC; Pentecost, AR; Fairchild EJ, II. (1987). Distribution of DNA and RNA content in the bone marrow and alveolar macrophages of rats after subchronic inhalation of formaldehyde. Environ Res 43: 191–202.2438128
Dallas, CE; Scott, MJ; Ward, JB, Jr; Theiss, JC. (1992). Cytogenetic analysis of pulmonary lavage and bone marrow cells of rats after repeated formaldehyde inhalation. J Appl Toxicol 12: 199–203. 10.1002/jat.2550120309.1378462
Dally, KA; Hanrahan, LP; Woodbury, MA; Kanarek, MS. (1981). Formaldehyde exposure in nonoccupational environments. Arch Environ Occup Health 36: 277–284. 10.1080/00039896.1981.10667638.
Dannemiller, KC; Murphy, JS; Dixon, SL; Pennell, KG; Suuberg, EM; Jacobs, DE; Sandel, M. (2013). Formaldehyde concentrations in household air of asthma patients determined using colorimetric detector tubes. Indoor Air 23: 285–294. 10.1111/ina.12024.23278296
Dawicki, W; Marshall, JS. (2007). New and emerging roles for mast cells in host defence [Review]. Curr Opin Immunol 19: 31–38. 10.1016/j.coi.2006.11.006.17126541
Day, JH; Lees, RE; Clark, RH; Pattee, PL. (1984). Respiratory response to formaldehyde and off-gas of urea formaldehyde foam insulation. Can Med Assoc J 131: 1061–1065.6388780
de Ceaurriz, J; Micillino, JC; Bonnet, P; Guenier, JP. (1981). [Prediction of the irritant effects of chemicals on the human respiratory tract: Advantages of an animal model]. Cah Notes Doc 102: 55–61.
De Flora, S. (1981). Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2: 283–298. 10.1093/carcin/2.4.283.7023727
De Flora, S; Zanacchi, P; Camoirano, A; Bennicelli, C; Badolati, GS. (1984). Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test [Review]. Mutat Res 133: 161–198. 10.1016/0165-1110(84)90016-2.6374443
De Jong, WH; Arts, JHE; De Klerk, A; Schijf, MA; Ezendam, J; Kuper, CF; Van Loveren, H. (2009). Contact and respiratory sensitizers can be identified by cytokine profiles following inhalation exposure. Toxicology 261: 103–111. 10.1016/j.tox.2009.04.057.19422874
de Serres, FJ; Brockman, HE. (1999). Comparison of the spectra of genetic damage in formaldehyde-induced ad-3 mutations between DNA repair-proficient and -deficient heterokaryons of Neurospora crassa. Mutat Res 437: 151–163. 10.1016/S1383-5742(99)00081-2.10556619
de Serres, FJ; Brockman, HE; Hung, CY. (1988). Effect of the homokaryotic state of the uvs-2 allele in Neurospora crassa on formaldehyde-induced killing and ad-3 mutation. Mutat Res 199: 235–242. 10.1016/0027-5107(88)90251-5.2966296
De Stefani, E; Boffetta, P; Brennan, P; Deneo-Pellegrini, H; Ronco, A; Gutiérrez, LP. (2005). Occupational exposures and risk of adenocarcinoma of the lung in Uruguay. Cancer Causes Control 16: 851–856. 10.1007/s10552-005-2819-4.16132795
de Vries, A; van Rijnsoever, C; Engels, F; Henricks, PA; Nijkamp, FP. (2001). The role of sensory nerve endings in nerve growth factor-induced airway hyperresponsiveness to histamine in guinea-pigs. Br J Pharmacol 134: 771–776. 10.1038/sj.bjp.0704310.11606317
Dean, JH; Lauer, LD; House, RV; Murray, MJ; Stillman, WS; Irons, RD; Steinhagen, WH; Phelps, MC; Adams, DO. (1984). Studies of immune fuction and host resistance in B6C3F1 mice exposed to formaldehyde. Toxicol Appl Pharmacol 72: 519–529. 10.1016/0041-008X(84)90129-7.6424265
Dell, L; Teta, MJ. (1995). Mortality among workers at a plastics manufacturing and research and development facility: 1946-1988. Am J Ind Med 28: 373–384. 10.1002/ajim.4700280307.7485191
Demkowicz-Dobrzanski, K; Castonguay, A. (1992). Modulation by glutathione of DNA strand breaks induced by 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone and its aldehyde metabolites in rat hepatocytes. Carcinogenesis 13: 1447–1454.1499096
Deng, J; Zhang, X; Liu, J; Wei, X; Liu, X; Ma, L; Zhao, Y; Li, Z. (2020). [Effects of gaseous formaldehyde fluctuating exposure on medical students’ subjective symptoms and pulmonary function]. Weisheng Yanjiu 49: 921–926. 10.19813/j.cnki.weishengyanjiu.2020.06.008.33413766
Dhareshwar, SS; Stella, VJ. (2008). Your prodrug releases formaldehyde: should you be concerned? No! J Pharm Sci 97: 4184–4193. 10.1002/jps.21319.18288723
DHGC (DuPont Haskell Global Centers). (2010). [Two Acute/ Subacute Inhalation toxicity studies].
Dickey, FH; Cleland, GH; Lotz, C. (1949). The role of organic peroxides in the induction of mutations. Proc Natl Acad Sci USA 35: 581–586.15391346
Dietrich, CJ; Richards, IS; Bernard, TE; Hammad, YY. (1996). Human stress protein response to formaldehyde exposure. Exp Toxicol Pathol 48: 518–519. 10.1016/S0940-2993(96)80071-6.8954337
Dillon, D; Combes, R; Zeiger, E. (1998). The effectiveness of Salmonella strains TA100, TA102 and TA104 for detecting mutagenicity of some aldehydes and peroxides. Mutagenesis 13: 19–26. 10.1093/mutage/13.1.19.9491389
Dingler, FA; Wang, M; Mu, A; Millington, CL; Oberbeck, N; Watcham, S; Pontel, LB; Kamimae-Lanning, AN; Langevin, F; Nadler, C; Cordell, RL; Monks, PS; Yu, R; Wilson, NK; Hira, A; Yoshida, K; Mori, M; Okamoto, Y; Okuno, Y; Muramatsu, H; Shiraishi, Y; Kobayashi, M; Moriguchi, T; Osumi, T; Kato, M; Miyano, S; Ito, E; Kojima, S; Yabe, H; Yabe, M; Matsuo, K; Ogawa, S; Göttgens, B; Hodskinson, MRG; Takata, M; Patel, KJ. (2020). Two aldehyde clearance systems are essential to prevent lethal formaldehyde accumulation in mice and humans. Mol Cell 80: 996–1012.e1019. 10.1016/j.molcel.2020.10.012.33147438
Dinsdale, D; Riley, RA; Verschoyle, RD. (1993). Pulmonary cytochrome P450 in rats exposed to formaldehyde vapor. Environ Res 62: 19–27. 10.1006/enrs.1993.1085.8100769
Divine, BJ; Barron, V. (1987). Texaco mortality study: III. A cohort study of producing and pipeline workers. Am J Ind Med 11: 189–202. 10.1002/ajim.4700110208.3826079
Doll, R; Peto, R. (1978). Cigarette smoking and bronchial carcinoma: Dose and time relationships among regular smoker and lifetime nonsmokers. J Epidemiol Community Health 32: 303–313.744822
Doolittle, DJ; Furlong, JW; Butterworth, BE. (1985). Assessment of chemically induced DNA repair in primary cultures of human bronchial epithelial cells. Toxicol Appl Pharmacol 79: 28–38. 10.1016/0041-008X(85)90365-5.4049406
Douglas, MP; Rogers, SO. (1998). DNA damage caused by common cytological fixatives. Mutat Res 401: 77–88. 10.1016/S0027-5107(97)00314-X.9639679
Dragan, YP; Hully, J; Baker, K; Crow, R; Mass, MJ; Pitot, HC. (1995). Comparison of experimental and theoretical parameters of the Moolgavkar-Venzon-Knudson incidence function for the stages of initiation and promotion in rat hepatocarcinogenesis. Toxicology 102: 161–175. 10.1016/0300-483X(95)03045-H.7482551
Dresp, J; Bauchinger, M. (1988). Direct analysis of the clastogenic effect of formaldehyde in unstimulated human lymphocytes by means of the premature chromosome condensation technique. Mutat Res 204: 349–352. 10.1016/0165-1218(88)90110-3.2449611
Duan, J; Kang, J; Qin, W; Deng, T; Liu, H; Li, B; Yu, W; Gong, S; Yang, X; Chen, M. (2018). Exposure to formaldehyde and diisononyl phthalate exacerbate neuroinflammation through NF-κB activation in a mouse asthma model. Ecotoxicol Environ Saf 163: 356–364. 10.1016/j.ecoenv.2018.07.089.30059880
Duan, J; Xie, J; Deng, T; Xie, X; Liu, H; Li, B; Chen, M. (2020). Exposure to both formaldehyde and high relative humidity exacerbates allergic asthma by activating the TRPV4-p38 MAPK pathway in Balb/c mice. Environ Pollut 256: 113375. 10.1016/j.envpol.2019.113375.31662264
Duan, YY. (2011). [Effects of overexpression of heat shock protein 70 on the damage induced by formaldehyde in vitro]. Zhonghua Laodong Weisheng Zhiyebing Zazhi 29: 349–352.21972530
Dumas, O; Boggs, KM; Quinot, C; Varraso, R; Zock, JP; Henneberger, PK; Speizer, FE; Le Moual, N; Camargo, CA. (2020). Occupational exposure to disinfectants and asthma incidence in U.S. nurses: A prospective cohort study. Am J Ind Med 63: 44–50. 10.1002/ajim.23067.31692020
Dykewicz, MS; Patterson, R; Cugell, DW; Harris, KE; Wu, AF. (1991). Serum IgE and IgG to formaldehyde-human serum albumin: Lack of relation to gaseous formaldehyde exposure and symptoms. J Allergy Clin Immunol 87: 48–57. 10.1016/0091-6749(91)90212-7.1991923
ECHA (European Chemicals Agency). (2012). Committee for risk assessment. RAC. Opinion proposing harmonized classification and labeling at EU level of formaldehyde. (CLH-O-0000003155-80-01/F). Helsinki, Finland. https://echa.europa.eu/documents/10162/b8dfa022-9544-72e8-dcaa-7491dff3c0d5.
Edling, C; Hellquist, H; Odkvist, L. (1987a). Occupational formaldehyde exposure and the nasal mucosa. Rhinology 25: 181–187.3672002
Edling, C; Hellquist, H; Odkvist, L. (1988). Occupational exposure to formaldehyde and histopathological changes in the nasal mucosa. Br J Ind Med 45: 761–765. 10.1136/oem.45.11.761.3203081
Edling, C; Järvholm, B; Andersson, L; Axelson, O. (1987b). Mortality and cancer incidence among workers in an abrasive manufacturing industry. Br J Ind Med 44: 57–59. 10.1136/oem.44.1.57.3814536
Edrissi, B; Taghizadeh, K; Dedon, PC. (2013a). Quantitative analysis of histone modifications: formaldehyde is a source of pathological n(6)-formyllysine that is refractory to histone deacetylases. PLoS Genet 9: e1003328. 10.1371/journal.pgen.1003328.23468656
Edrissi, B; Taghizadeh, K; Moeller, BC; Kracko, D; Doyle-Eisele, M; Swenberg, JA; Dedon, PC. (2013b). Dosimetry of N⁶-formyllysine adducts following [¹³C²H₂]-formaldehyde exposures in rats. Chem Res Toxicol 26: 1421–1423. 10.1021/tx400320u.24087891
Edrissi, B; Taghizadeh, K; Moeller, BC; Yu, R; Kracko, D; Doyle-Eisele, M; Swenberg, JA; Dedon, PC. (2017). N6-Formyllysine as a Biomarker of Formaldehyde Exposure: Formation and Loss of N6-Formyllysine in Nasal Epithelium in Long-Term, Low-Dose Inhalation Studies in Rats. Chem Res Toxicol 30: 1572–1576. 10.1021/acs.chemrestox.7b00075.28692800
Egle, JL, Jr. (1972). Retention of inhaled formaldehyde, propionaldehyde, and acrolein in the dog. Arch Environ Health 25: 119–124. 10.1080/00039896.1972.10666147.5045063
EHS Consultants Ltd. (EHS Consultants Limited). (1999). Consultancy study for indoor air pollution in offices and public places in Hong Kong (Agreement no. CE 14/95). Hong Kong: Environmental Protection Department.
El-Feky, AA; Kabbash, IA; Zayet, HH; El-Sallamy, RM. (2020). Health disorders and safety measures among workers in Tanta Flax and Oil Company, Egypt. Environ Sci Pollut Res Int 28: 13981–13990. 10.1007/s11356-020-11588-0.33200388
Elenkov, IJ. (2004). Glucocorticoids and the Th1/Th2 balance [Review]. Ann N Y Acad Sci 1024: 138–146. 10.1196/annals.1321.010.15265778
Emri, G; Schaefer, D; Held, B; Herbst, C; Zieger, W; Horkay, I; Bayerl, C. (2004). Low concentrations of formaldehyde induce DNA damage and delay DNA repair after UV irradiation in human skin cells. Exp Dermatol 13: 305–315. 10.1111/j.0906-6705.2004.00157.x.15140021
Environment Canada (Environment Canada). (2000). Priority substances list assessment report. Formaldehyde. Ottawa, Canada: Health Canada. http://publications.gc.ca/collections/Collection/En40-215-50E.pdf.
Eom, HJ; Liu, YD; Kwak, GS; Heo, M; Song, KS; Chung, YD; Chon, TS; Choi, J. (2017). Inhalation toxicity of indoor air pollutants in Drosophila melanogaster using integrated transcriptomics and computational behavior analyses. Sci Rep 7: 46473. 10.1038/srep46473.28621308
Epstein, SS; Arnold, E; Andrea, J; Bass, W; Bishop, Y. (1972). Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23: 288–325. 10.1016/0041-008X(72)90192-5.5074577
Epstein, SS; Shafner, H. (1968). Chemical mutagens in the human environment. Nature 219: 385–387. 10.1038/219385a0.5662155
Erb, KJ; Le Gros, G. (1996). The role of Th2 type CD4+ T cells and Th2 type CD8+ T cells in asthma [Review]. Immunol Cell Biol 74: 206–208. 10.1038/icb.1996.29.8724011
Erdei, E; Bobvos, J; Brózik, M; Páldy, A; Farkas, I; Vaskövi, E; Rudnai, P. (2003). Indoor air pollutants and immune biomarkers among Hungarian asthmatic children. Arch Environ Occup Health 58: 337–347.
Ericson, A; Eriksson, M; Källén, B; Westerholm, P; Zetterström, R. (1984). Delivery outcome of women working in laboratories during pregnancy. Arch Environ Health 39: 5–10.6712285
Esterbauer, H; Cheeseman, KH; Dianzani, MU; Poli, G; Slater, TF. (1982). Separation and characterization of the aldehydic products of lipid peroxidation stimulated by ADP-Fe2+ in rat liver microsomes. Biochem J 208: 129–140.7159389
Ezratty, V; Bonay, M; Neukirch, C; Orset-Guillossou, G; Dehoux, M; Koscienlny, S; Cabanes, PA; Lambrozo, J; Aubier, M. (2007). Effect of formaldehyde on asthmatic response to inhaled allergen challenge. Environ Health Perspect 115: 210–214. 10.1289/ehp.9414.17384766
Fajac, I; Braunstein, G; Ickovic, MR; Lacronique, J; Frossard, N. (1995). Selective recruitment of eosinophils by substance P after repeated allergen exposure in allergic rhinitis. Allergy 50: 970–975. 10.1111/j.1398-9995.1995.tb02509.x.8834826
Falk, JE; Juto, JE; Stridh, G; Bylin, G. (1994). Dose-response study of formaldehyde on nasal mucosa swelling. A study on residents with nasal distress at home. Am J Rhinol Allergy 8: 143–146. 10.2500/105065894781874412.
Fang, F; Quinlan, P; Ye, W; Barber, MK; Umbach, DM; Sandler, DP; Kamel, F. (2009). Workplace exposures and the risk of amyotrophic lateral sclerosis. Environ Health Perspect 117: 1387–1392. 10.1289/ehp.0900580.19750102
Fang, J; Li, DH; Yu, XQ; Lv, MQ; Bai, LZ; Du, LZ; Zhou, DX. (2015). Formaldehyde exposure inhibits the expression of mammalian target of rapamycin in rat testis. Toxicol Ind Health 32: 1882–1890. 10.1177/0748233715592992.
Farrand, KF; Fridman, M; Stillman, IÖ; Schaumberg, DA. (2017). Prevalence of diagnosed dry eye disease in the United States among adults aged 18 years and older. Am J Ophthalmol 182: 90–98. 10.1016/j.ajo.2017.06.033.28705660
Fenech, M. (1993). The cytokinesis-block micronucleus technique: a detailed description of the method and its application to genotoxicity studies in human populations [Review]. Mutat Res 285: 35–44.7678131
Fenech, M. (2000). The in vitro micronucleus technique [Review]. Mutat Res 455: 81–95.11113469
Fenech, M. (2007). Cytokinesis-block micronucleus cytome assay. Nat Protoc 2: 1084–1104. 10.1038/nprot.2007.77.17546000
Fenech, M; Chang, WP; Kirsch-Volders, M; Holland, N; Bonassi, S; Zeiger, E; project, HM. (2003). HUMN project: detailed description of the scoring criteria for the cytokinesis-block micronucleus assay using isolated human lymphocyte cultures [Comment]. Mutat Res 534: 65–75.12504755
Fenech, M; Morley, AA. (1985). Measurement of micronuclei in lymphocytes. Mutat Res 147: 29–36.3974610
Fenech, M; Morley, AA. (1986). Cytokinesis-block micronucleus method in human lymphocytes: effect of in vivo ageing and low dose X-irradiation. Mutat Res 161: 193–198.3724773
Fennell, TR. (1994). Development of methods for measuring biological markers of formaldehyde exposure (pp. 1–20; discussion 21–26). Cambridge, MA: Health Effects Institute.
Feron, VJ; Bruyntjes, JP; Woutersen, RA; Immel, HR; Appelman, LM. (1988). Nasal tumours in rats after short-term exposure to a cytotoxic concentration of formaldehyde. Cancer Lett 39: 101–111. 10.1016/0304-3835(88)90045-6.3345504
Feron, VJ; Immel, HR; Wilmer, JWG, M; Woutersen, RA; Zwart, A. (1987). Nasal Tumours in Rats after Severe Injury to the Nasal Mucosa and Exposure to Formaldehyde Vapour: Preliminary Results (pp. 8–12). (NIOSH/00176121). Feron, VJ; Immel, HR; Wilmer, JWGM; Woutersen, RA; Zwart, A.
Ferris, BG. (1978). Epidemiology standardization project (American Thoracic Society). Am Rev Respir Dis 118: 1–120.
Fiddler, W; Miller, AJ; Pensabene, JW; Doerr, RC. (1984). Investigation on the mutagenicity of N-nitrosothiazolidine using the Ames Salmonella test. In IK O’Neill; RC von Borstel; CT Miller; J Long; H Bartsch (Eds.), N-nitroso compounds: Occurrence, biological effects and relevance to human cancer (pp. 95–100). Lyon, France: International Agency for Research on Cancer.
Finkelman, FD. (2007). Anaphylaxis: lessons from mouse models [Review]. J Allergy Clin Immunol 120: 506–515; quiz 516-507. 10.1016/j.jaci.2007.07.033.17765751
FJ, C. (2009). Natural killer cells in infection and inflammation of the lung [Review]. Immunology 128: 151–163. 10.1111/j.1365-2567.2009.03167.x.19740372
Flamant-Hulin, M; Caillaud, D; Sacco, P; Pénard-Morand, C; Annesi-Maesano, I. (2010). Air pollution and increased levels of fractional exhaled nitric oxide in children with no history of airway damage. J Toxicol Environ Health A 73: 272–283. 10.1080/15287390903249206.20077297
Fleig, I; Petri, N; Stocker, WG; Thiess, AM. (1982). Cytogenetic analyses of blood lymphocytes of workers exposed to formaldehyde in formaldehyde manufacturing and processing. J Occup Med 24: 1009–1012.7153801
Fleisher, JM. (1987). Medical students’ exposure to formaldehyde in gross anatomy laboratories. N Y State J Med 87: 385–388.3476866
Fló-Neyret, C; Lorenzi-Filho, G; Macchione, M; Garcia, ML; Saldiva, PH. (2001). Effects of formaldehyde on the frog’s mucociliary epithelium as a surrogate to evaluate air pollution effects on the respiratory epithelium. Braz J Med Biol Res 34: 639–643. 10.1590/S0100-879X2001000500012.11323751
Fontignie-Houbrechts, N. (1981). Genetic effects of formaldehyde in the mouse. Mutat Res 88: 109–114. 10.1016/0165-1218(81)90095-1.7207492
Fontignie-Houbrechts, N; Moutschen-Dahmen, M; Degraeve, N; Gloor, H. (1982). Genetic effects in the mouse of formaldehyde in combination with adenosine and hydrogen peroxide. Mutat Res 104: 371–376. 10.1016/0165-7992(82)90172-5.7110172
Fornace, AJ. (1982). Detection of DNA single-strand breaks produced during the repair of damage by DNA-protein cross-linking agents. Cancer Res 42: 145–149.7198506
Fornace, AJ; Lechner, JF; Grafstrom, RC; Harris, CC. (1982). DNA repair in human bronchial epithelial cells. Carcinogenesis 3: 1373–1377. 10.1093/carcin/3.12.1373.7151252
Fox, CH; Johnson, FB; Whiting, J; Roller, PP. (1985). Formaldehyde fixation [Review]. J Histochem Cytochem 33: 845–853.3894502
Franklin, P; Dingle, P; Stick, S. (2000). Raised exhaled nitric oxide in healthy children is associated with domestic formaldehyde levels. Am J Respir Crit Care Med 161: 1575–1759. 10.1164/ajrccm.161.5.9905061.
Franklin, P; Tan, M; Hemy, N; Hall, GL. (2019). Maternal Exposure to Indoor Air Pollution and Birth Outcomes. Int J Environ Res Public Health 16. 10.3390/ijerph16081364.
Franks, SJ. (2005). A mathematical model for the absorption and metabolism of formaldehyde vapour by humans. Toxicol Appl Pharmacol 206: 309–320. 10.1016/j.taap.2004.11.012.16039942
Fransman, W; Mclean, D; Douwes, J; Demers, PA; Leung, V; Pearce, N. (2003). Respiratory symptoms and occupational exposures in New Zealand plywood mill workers. Ann Occup Hyg 47: 287–295. 10.1093/annhyg/meg046.12765869
Frazelle, JH; Abernethy, DJ; Boreiko, CJ. (1983). Weak promotion of C3H/10T1/2 cell transformation by repeated treatments with formaldehyde. Cancer Res 43: 3236–3239.6850633
Fryzek, JP; Chadda, BK; Cohen, SS; Marano, D; White, K; Steinwandel, M; Mclaughlin, JK. (2005). Retrospective cohort mortality study of workers engaged in motion picture film processing. J Occup Environ Med 47: 278–286. 10.1097/01.jom.0000155712.22617.42.15761324
Fsadni, P; Bezzina, F; Fsadni, C; Montefort, S. (2018). Impact of School Air Quality on Children’s Respiratory Health. Indian J Occup Environ Med 22: 156–162. 10.4103/ijoem.IJOEM_95_18.30647518
Fujii, K; Tsuji, K; Matsuura, H; Okazaki, F; Takahashi, S; Arata, J; Iwatsuki, K. (2005). Effect of formaldehyde gas exposure in a murine allergic contact hypersensitivity model. Immunopharmacol Immunotoxicol 27: 163–175. 10.1081/IPH-51768.15803868
Fujimaki, H; Kurokawa, Y; Kakeyama, M; Kunugita, N; Fueta, Y; Fukuda, T; Hori, H; Arashidani, K. (2004a). Inhalation of low-level formaldehyde enhances nerve growth factor production in the hippocampus of mice. Neuroimmunomodulation 11: 373–375. 10.1159/000080147.15467352
Fujimaki, H; Kurokawa, Y; Kunugita, N; Kikuchi, M; Sato, F; Arashidani, K. (2004b). Differential immunogenic and neurogenic inflammatory responses in an allergic mouse model exposed to low levels of formaldehyde. Toxicology 197: 1–13. 10.1016/j.tox.2003.11.015.15003329
Fujimaki, H; Shiraishi, F; Katayama, N. (1992). Enhancement of histamine release from rat peritoneal mast cells exposed to formaldehyde. Inhal Toxicol 4: 125–136. 10.3109/08958379209145309.
Galloway, SM; Bloom, AD; Resnick, M; Margolin, BH; Nakamura, F; Archer, P; Zeiger, E. (1985). Development of a standard protocol for in vitro cytogenetic testing with Chinese hamster ovary cells: Comparison of results for 22 compounds in two laboratories. Environ Mutagen 7: 1–51. 10.1002/em.2860070102.
Gamble, JF; Mcmichael, AJ; Williams, T; Battigelli, M. (1976). Respiratory function and symptoms: an environmental-epidemiological study of rubber workers exposed to a phenolformaldehyde type resin. Am Ind Hyg Assoc J 37: 499–513. 10.1080/0002889768507508.1008033
Gammage, RB; Hawthorne, AR. (1985). Current status of measurement techniques and concentrations of formaldehyde in residences. In V Turoski (Ed.), Formaldehyde: Analytical Chemistry and Toxicology (pp. 117–130). Washington, DC: ACS Publications. 10.1021/ba-1985-0210.ch009.
García-Calderón, CB; Bejarano-García, JA; Tinoco-Gago, I; Castro, MJ; Moreno-Gordillo, P; Piruat, JI; Caballero-Velázquez, T; Pérez-Simón, JA; Rosado, IV. (2018). Genotoxicity of tetrahydrofolic acid to hematopoietic stem and progenitor cells. Cell Death Differ 25: 1967–1979. 10.1038/s41418-018-0089-4.29511342
Gardner, MJ; Pannett, B; Winter, PD; Cruddas, AM. (1993). A cohort study of workers exposed to formaldehyde in the British chemical industry: An update. Br J Ind Med 50: 827–834. 10.1136/oem.50.9.827.8398877
Gardner, RJ; Burgess, BA; Kennedy, GL, Jr. (1985). Sensory irritation potential of selected nasal tumorigens in the rat. Food Chem Toxicol 23: 87–92. 10.1016/0278-6915(85)90225-X.4038687
Garrett, MH; Hooper, MA; Hooper, BM; Rayment, PR; Abramson, MJ. (1999a). Increased risk of allergy in children due to formaldehyde exposure in homes. Allergy 54: 330–337. 10.1034/j.1398-9995.1999.00763.x.10371091
Garrett, MH; Hooper, MA; Hooper, BM; Rayment, PR; Abramson, MJ. (1999b). Increased risk of allergy in children due to formaldehyde exposure in homes. Errata [Erratum]. Allergy 54: 1327.
Gasteiger, G; Rudensky, AY. (2014). Interactions between innate and adaptive lymphocytes [Review]. Nat Rev Immunol 14: 631–639. 10.1038/nri3726.25132095
Gavala, ML; Bashir, H; Gern, JE. (2013). Virus/Allergen Interactions in Asthma. Curr Allergy Asthma Rep 13: 298–307. 10.1007/s11882-013-0344-1.23475539
Gaylor, DW; Zheng, Q. (1996). Risk assessment of nongenotoxic carcinogens based upon cell proliferation/death rates in rodents. Risk Anal 16: 221–225.8638041
Ge, J; Yang, H; Lu, X; Wang, S; Zhao, Y; Huang, J; Xi, Z; Zhang, L; Li, R. (2020a). Combined exposure to formaldehyde and PM2.5: Hematopoietic toxicity and molecular mechanism in mice. Environ Int 144: 106050. 10.1016/j.envint.2020.106050.32861163
Ge, P; Zhang, X; Yang, YQ; Lv, MQ; Zhou, DX. (2020b). Long-term exposure to formaldehyde induced down-regulation of SPO11 in rats. Inhal Toxicol 33: 1–10. 10.1080/08958378.2020.1859652.
Ge, S; Yan, B; Huang, J; Chen, Y; Chen, M; Yang, X; Wu, Y; Shen, D; Ma, P. (2019). Diisodecyl phthalate aggravates the formaldehyde-exposure-induced learning and memory impairment in mice. Food Chem Toxicol 126: 152–161. 10.1016/j.fct.2019.02.024.30790713
Gee, IL; Watson, AFR; Tavernier, G; Stewart, LJ; Fletcher, G; Niven, RM. (2005). Indoor air quality, environmental tobacco smoke and asthma: A case control study of asthma in a community population. Indoor Built Environ 14: 215–219. 10.1177/1420326X05054288.
Gentry, PR; Rodricks, JV; Turnbull, D; Bachand, A; Van Landingham, C; Shipp, AM; Albertini, RJ; Irons, R. (2013). Formaldehyde exposure and leukemia: Critical review and reevaluation of the results from a study that is the focus for evidence of biological plausibility [Review]. Crit Rev Toxicol 43: 661–670. 10.3109/10408444.2013.818618.23902349
Georgieva, AV; Kimbell, JS; Schlosser, PM. (2003). A distributed-parameter model for formaldehyde uptake and disposition in the rat nasal lining. Inhal Toxicol 15: 1435–1463. 10.1080/08958370390249085.14648358
Gerberich, HR; Seaman, GC. (2013). Formaldehyde. In JI Kroshwitz; M Howe-Grant (Eds.), Kirk-Othmer encyclopedia of chemical technology (4th ed., pp. 929–951). New York, NY: John Wiley & Sons.
Gerde, P; Cheng, YS; Medinsky, MA. (1991). In vivo deposition of ultrafine aerosols in the nasal airway of the rat. Toxicol Sci 16: 330–336. 10.1016/0272-0590(91)90117-m.
Gérin, M; Siemiatycki, J; Nadon, L; Dewar, R; Krewski, D. (1989). Cancer risks due to occupational exposure to formaldehyde: Results of a multi-site case-control study in Montreal. Int J Cancer 44: 53–58. 10.1002/ijc.2910440110.2744897
Ghelli, F; Buglisi, M; Bellisario, V; Santovito, A; Bono, R. (2020). Formaldehyde in hospitals can still represent a risk factor. Oxidative stress and GSTT1 polymorphism [Abstract]. Eur J Public Health 30. 10.1093/eurpub/ckaa166.340.
Giavina-Bianchi, P; Aun, MV; Takejima, P; Kalil, J; Agondi, RC. (2016). United airway disease: current perspectives [Review]. Journal of Asthma and Allergy 9: 93–100. 10.2147/JAA.S81541.27257389
Gieroba, ZJ; Yu, YH; Blessing, WW. (1994). Vasoconstriction induced by inhalation of irritant vapour is associated with appearance of Fos protein in C1 catecholamine neurons in rabbit medulla oblongata. Brain Res 636: 157–161. 10.1016/0006-8993(94)90192-9.7908852
Gilbert, NL; Gauvin, D; Guay, M; Heroux, ME; Dupuis, G; Legris, M; Chan, CC; Dietz, RN; Levesque, B. (2006). Housing characteristics and indoor concentrations of nitrogen dioxide and formaldehyde in Quebec City, Canada. Environ Res 102: 1–8. 10.1016/j.envres.2006.02.007.16620807
Gilbert, NL; Guay, M; David Miller, J; Judek, S; Chan, CC; Dales, RE. (2005). Levels and determinants of formaldehyde, acetaldehyde, and acrolein in residential indoor air in Prince Edward Island, Canada. Environ Res 99: 11–17. 10.1016/j.envres.2004.09.009.16053923
Ginsberg, GL; Foos, BP; Firestone, MP. (2005). Review and analysis of inhalation dosimetry methods for application to children’s risk assessment [Review]. J Toxicol Environ Health A 68: 573–615. 10.1080/15287390590921793.15901090
Glaser, R; Kiecolt-Glaser, JK. (2005). Stress-induced immune dysfunction: implications for health [Review]. Nat Rev Immunol 5: 243–251. 10.1038/nri1571.15738954
Gocke, E; King, MT; Eckhardt, K; Wild, D. (1981). [Mutagenicity of cosmetics ingredients licensed by the European communities]. Mutat Res 90: 91–109. 10.1016/0165-1218(81)90072-0.6799819
Gofmekler, VA. (1968). Effect on embryonic development of benzene and formaldehyde in inhalation experiments. Hyg Sanit 33: 327–332.
Gofmekler, VA; Bonashevskaya, TI. (1969). Experimental studies of teratogenic properties of formaldehyde, based on pathological investigations. Hyg Sanit 34: 266–268.
Golalipour, MJ; Azarhoush, R; Ghafari, S; Gharravi, AM; Fazeli, SA; Davarian, A. (2007). Formaldehyde exposure induces histopathological and morphometric changes in the rat testis. Folia Morphol (Warsz) 66: 167–171.17985313
Golalipour, MJ; Kord, H; Ghafari, S; Gharravi, AM; Davarian, A; Fazeli, SA; Azarhoush, R. (2008). Morphometric alterations of the rat spleen following formaldehyde exposure. Folia Morphol (Warsz) 67: 19–23.18335409
Goldmacher, VS; Thilly, WG. (1983). Formaldehyde is mutagenic for cultured human cells. Mutat Res 116: 417–422. 10.1016/0165-1218(83)90080-0.6835255
Goldsworthy, TL; Butterworth, BE; Maronpot, RR. (1993). Concepts, labeling procedures, and design of cell proliferation studies relating to carcinogenesis [Review]. Environ Health Perspect 101 Suppl 5: 59–65. 10.1289/ehp.93101s559.
Goldsworthy, TL; Morgan, KT; Popp, JA; Butterworth, BE. (1991). Guidelines for measuring chemically induced cell proliferation in specific rodent target organs. Prog Clin Biol Res 369: 253–284.1946524
Gomaa, M; Elmesallamy, GE; Sameer, MM. (2012). Evaluation of genotoxic effects of formaldehyde in adult albino rats and its implication in case of human exposure. Life Science Journal 9: 3085–3093.
Gonzalez-Rivera, JC; Sherman, MW; Wang, DS; Chuvalo-Abraham, JCL; Hildebrandt Ruiz, L; Contreras, LM. (2020). RNA oxidation in chromatin modification and DNA-damage response following exposure to formaldehyde. Sci Rep 10: 16545. 10.1038/s41598-020-73376-7.33024153
Gordon, CJ; Spencer, PJ; Hotchkiss, J; Miller, DB; Hinderliter, PM; Pauluhn, J. (2008). Thermoregulation and its influence on toxicity assessment. Toxicology 244: 87–97. 10.1016/j.tox.2007.10.030.18096291
Górski, P; Krakowiak, A. (1991). Formaldehyde--induced bronchial asthma--does it really exist? Pol J Occup Med Environ Health 4: 317–320.1817680
Gostner, JM; Zeisler, J; Alam, MT; Gruber, P; Fuchs, D; Becker, K; Neubert, K; Kleinhappl, M; Martini, S; Überall, F. (2016). Cellular reactions to long-term volatile organic compound (VOC) exposures. Sci Rep 6: 37842. 10.1038/srep37842.27905399
Gottschling, LM; Beaulieu, HJ; Melvin, WW. (1984). Monitoring of formic acid in urine of humans exposed to low levels of formaldehyde. Am Ind Hyg Assoc J 45: 19–23. 10.1080/15298668491399299.6702592
Graf, RA; Kater, SB; Gordon, H. (1999). Prolonged Cytosolic Calcium Elevations in Growth Cones Contacting Muscle. Dev Neurosci 21: 409–416. 10.1159/000017408.10640859
Grafstrom, RC. (1990). In vitro studies of aldehyde effects related to human respiratory carcinogenesis. Mutat Res 238: 175–184.2342511
Grafstrom, RC; Fornace, A, Jr; Harris, CC. (1984). Repair of DNA damage caused by formaldehyde in human cells. Cancer Res 44: 4323–4327.6467194
Grafstrom, RC; Fornace, AJ, Jr; Autrup, H; Lechner, JF; Harris, CC. (1983). Formaldehyde damage to DNA and inhibition of DNA repair in human bronchial cells. Science 220: 216–218. 10.1126/science.6828890.6828890
Grafström, RC; Hsu, IC; Harris, CC. (1993). Mutagenicity of formaldehyde in Chinese hamster lung fibroblasts: Synergy with ionizing radiation and N-nitroso-N-methylurea. Chem Biol Interact 86: 41–49. 10.1016/0009-2797(93)90110-K.8431964
Grafstrom, RC; Sundqvist, K; Dypbukt, JM; Hybbinette, SA; Harris, CC. (1986). CYTOTOXIC AND GENOTOXIC EFFECTS OF ALDEHYDES IN CULTURED HUMAN BRONCHIAL CELLS (pp. BASEL). (BIOSIS/87/05969). Grafstrom, RC; Sundqvist, K; Dypbukt, JM; Hybbinette, SA; Harris, CC.
Grafstrom, RC; Willey, JC; Harris, CC. (1985). PATHOBIOLOGICAL EFFECT OF TOBACCO SMOKE CONDENSATE FRACTIONS AND SMOKE-RELATED ALDEHYDES IN CULTURED NORMAL HUMAN BRONCHIAL EPITHELIAL CELLS (pp. 6–13). (BIOSIS/85/10935). Grafstrom, RC; Willey, JC; Harris, CC.
Grafström, RC; Willey, JC; Sundqvist, K; Harris, CC. (1986). Pathobiological effects of tobacco smoke-related aldehydes in cultured human bronchial epithelial cells. In D Hoffman; CC Harris (Eds.), Mechanisms in Tobacco Carcinogenesis, Banbury Report 23 (pp. 273–285). Cold Springs Harbor, NY: CSH Press.
Grammer, LC; Harris, KE; Shaughnessy, MA; Sparks, P; Ayars, GH; Altman, LC; Patterson, R. (1990). Clinical and immunologic evaluation of 37 workers exposed to gaseous formaldehyde. J Allergy Clin Immunol 86: 177–181. 10.1016/S0091-6749(05)80063-6.2384647
Grasl-Kraupp, B; Luebeck, G; Wagner, A; Löw-Baselli, A; de Gunst, M; Waldhör, T; Moolgavkar, S; Schulte-Hermann, R. (2000). Quantitative analysis of tumor initiation in rat liver: role of cell replication and cell death (apoptosis). Carcinogenesis 21: 1411–1421. 10.1093/carcin/21.7.1411.10874021
Graves, RJ; Callander, RD; Green, T. (1994). The role of formaldehyde and S-chloromethylglutathione in the bacterial mutagenicity of methylene chloride. Mutat Res 320: 235–243. 10.1016/0165-1218(94)90050-7.7508089
Graves, RJ; Trueman, P; Jones, S; Green, T. (1996). DNA sequence analysis of methylene chloride-induced HPRT mutations in Chinese hamster ovary cells: Comparison with the mutation spectrum obtained for 1,2-dibromoethane and formaldehyde. Mutagenesis 11: 229–233. 10.1093/mutage/11.3.229.8671744
Green, DJ; Bascom, R; Healey, EM; Hebel, JR; Sauder, LR; Kulle, TJ. (1989). Acute pulmonary response in healthy, nonsmoking adults to inhalation of formaldehyde and carbon. J Toxicol Environ Health 28: 261–275. 10.1080/15287398909531347.2585534
Green, DJ; Sauder, LR; Kulle, TJ; Bascom, R. (1987). Acute response to 3.0 ppm formaldehyde in exercising healthy nonsmokers and asthmatics. Am Rev Respir Dis 135: 1261–1266. 10.1164/arrd.1987.135.6.1261.3592401
Greenfeder, S; Umland, SP; Cuss, FM; Chapman, RW; Egan, RW. (2001). Th2 cytokines and asthma. The role of interleukin-5 in allergic eosinophilic disease [Review]. Respir Res 2: 71–79. 10.1186/rr41.11686868
Grimsrud, DT; Lipschutz, RD; Girman, JR. (1983). Indoor air quality in energy efficient residences. In PJ Walsh; CS Dudney; ED Copenhaver (Eds.), Indoor air quality (pp. 69–85). Boca Raton, FL: CRC Press. https://www.crcpress.com/Indoor-Air-Quality/Walsh-Dudney-Copenhaver/9780849350153.
Gross, EA; Swenberg, JA; Fields, S; Popp, JA. (1982). Comparative morphometry of the nasal cavity in rats and mice. J Anat 135: 83–88.7130058
Groten, JP; Schoen, ED; van Bladeren, PJ; Kuper, CF; van Zorge, JA; Feron, VJ. (1997). Subacute toxicity of a mixture of nine chemicals in rats: detecting interactive effects with a fractionated two-level factorial design. Fundam Appl Toxicol 36: 15–29. 10.1006/faat.1996.2281.9073463
Gu, Y; Fujimiya, Y; Kunugita, N. (2008). Long-term exposure to gaseous formaldehyde promotes allergen-specific IgE-mediated immune responses in a murine model. Hum Exp Toxicol 27: 37–43. 10.1177/0960327108088973.18480147
Guilmette, RA; Cheng, YS; Griffith, WC. (1997). Characterising the variability in adult human nasal airway dimensions. Ann Occup Hyg 41: 491–496.
Güleç, M; Songur, A; Sahin, S; Ozen, OA; Sarsilmaz, M; Akyol, O. (2006). Antioxidant enzyme activities and lipid peroxidation products in heart tissue of subacute and subchronic formaldehyde-exposed rats: a preliminary study. Toxicol Ind Health 22: 117–124. 10.1191/0748233706th248oa.16716041
Guseva, VA. (1973a). Study of the gonadotropic effect in male rats exposed to formaldehyde, supplied simultaneously in air and water. Gig Sanit 37: 102–103.
Guseva, VA. (1973b). [Study of the gonadotropic effect in male rats under the effect of formaldehyde administered simultaneously with air and water]. Gig Sanit 37: 102–103.
Gustavsson, P; Jakobsson, R; Johansson, H; Lewin, F; Norell, S; Rutkvist, LE. (1998). Occupational exposures and squamous cell carcinoma of the oral cavity, pharynx, larynx, and oesophagus: A case-control study in Sweden. Occup Environ Med 55: 393–400.9764099
Guyton, AC. (1991). Textbook of medical physiology (8th ed.). Philadelphia, PA: W.B. Saunders Co.
Hagiwara, M; Watanabe, E; Barrett, JC; Tsutsui, T. (2006). Assessment of genotoxicity of 14 chemical agents used in dental practice: Ability to induce chromosome aberrations in Syrian hamster embryo cells. Mutat Res 603: 111–120. 10.1016/j.mrgentox.2005.08.011.16406784
Hagmar, L; Bellander, T; Englander, V; Ranstam, J; Attewell, R; Skerfving, S. (1986). Mortality and cancer morbidity among workers in a chemical factory. Scand J Work Environ Health 12: 545–551. 10.5271/sjweh.2102.3823803
Hall, A; Harrington, JM; Aw, TC. (1991). Mortality study of British pathologists. Am J Ind Med 20: 83–89. 10.1002/ajim.4700200108.1867220
Hamaguchi, F; Tsutui, T. (2000). Assessment of genotoxicity of dental antiseptics: Ability of phenol, guaiacol, p-phenolsulfonic acid, sodium hypochlorite, p-chlorophenol, m-cresol or formaldehyde to induce unscheduled DNA synthesis in cultured Syrian hamster embryo cells. Jpn J Pharmacol 83: 273–276. 10.1254/jjp.83.273.10952079
Hamelmann, E; Tadeda, K; Oshiba, A; Gelfand, EW. (1999). Role of IgE in the development of allergic airway inflammation and airway hyperresponsiveness--a murine model [Review]. Allergy 54: 297–305. 10.1034/j.1398-9995.1999.00085.x.10371087
Hamelmann, E; Vella, AT; Oshiba, A; Kappler, JW; Marrack, P; Gelfand, EW. (1997). Allergic airway sensitization induces T cell activation but not airway hyperresponsiveness in B cell-deficient mice. Proc Natl Acad Sci USA 94: 1350–1355.9037056
Han, RT; Back, SK; Lee, H; Lee, J; Kim, HY; Kim, HJ; Na, HS. (2016). Formaldehyde-Induced Aggravation of Pruritus and Dermatitis Is Associated with the Elevated Expression of Th1 Cytokines in a Rat Model of Atopic Dermatitis. PLoS ONE 11: e0168466. 10.1371/journal.pone.0168466.28005965
Han, SP; Zhou, DX; Lin, P; Qin, Z; An, L; Zheng, LR; Lei, L. (2015). Formaldehyde exposure induces autophagy in testicular tissues of adult male rats. Environ Toxicol 30: 323–331. 10.1002/tox.21910.24142868
Hanna, LM; Lou, SR; Su, S; Jarabek, AM. (2001). Mass transport analysis: inhalation RfC methods framework for interspecies dosimetric adjustment. Inhal Toxicol 13: 437–463. 10.1080/08958370119198.11295872
Hanrahan, LP; Dally, KA; Anderson, HA; Kanarek, MS; Rankin, J. (1984). Formaldehyde vapor in mobile homes: A cross sectional survey of concentrations and irritant effects. Am J Public Health 74: 1026–1027. 10.2105/ajph.74.9.1026.6331773
Hansen, J; Olsen, JH. (1995). Formaldehyde and cancer morbidity among male employees in Denmark. Cancer Causes Control 6: 354–360. 10.1007/BF00051411.7548723
Hansen, J; Olsen, JH; Larsen, AI. (1994). Cancer morbidity among employees in a Danish pharmaceutical plant. Int J Epidemiol 23: 891–898. 10.1093/ije/23.5.891.7860168
Hardell, L; Johansson, B; Axelson, O. (1982). Epidemiological study of nasal and nasopharyngeal cancer and their relation to phenoxy acid or chlorophenol exposure. Am J Ind Med 3: 247–257. 10.1002/ajim.4700030304.6303119
Hare, DA; Margosian, RL; Groah, WJ; 3rd, AS; Schweer, LG; Koontz, MD. (1996). Evaluating the contribution of UF-bonded building materials to indoor formaldehyde levels in a newly constructed house.
Harkema, JR; Carey, SA; Wagner, JG. (2006). The nose revisited: A brief overview of the comparative structure, function, and toxicologic pathology of the nasal epithelium [Review]. Toxicol Pathol 34: 252–269. 10.1080/01926230600713475.16698724
Harrington, JM; Oakes, D. (1984). Mortality study of British pathologists 1974-80. Occup Environ Med 41: 188–191. 10.1136/oem.41.2.188.
Harrington, JM; Shannon, HS. (1975). Mortality study of pathologists and medical laboratory technicians. Br Med J 4: 329–332.1192055
Harving, H; Korsgaard, J; Dahl, R; Pedersen, OF; Molhave, L. (1986). Low concentrations of formaldehyde in bronchial asthma: a study of exposure under controlled conditions. Br Med J 293: 310.3089500
Harving, H; Korsgaard, J; Pedersen, OF; Mølhave, L; Dahl, R. (1990). Pulmonary function and bronchial reactivity in asthmatics during low-level formaldehyde exposure. Lung 168: 15–21. 10.1007/BF02719669.2105409
Haseman, JK. (1995). Data analysis: statistical analysis and use of historical control data. Regul Toxicol Pharmacol 21: 52–59. 10.1006/rtph.1995.1009.7784636
Hastie, AT; Patrick, H; Fish, JE. (1990). Inhibition and recovery of mammalian respiratory ciliary function after formaldehyde exposure. Toxicol Appl Pharmacol 102: 282–291. 10.1016/0041-008X(90)90027-R.2137268
Hauptmann, M; Lubin Jay, H; Stewart, PA; Hayes, RB; Blair, A. (2003). Mortality from lymphohematopoietic malignancies among workers in formaldehyde industries. J Natl Cancer Inst 95: 1615–1623. 10.1093/jnci/djg083.14600094
Hauptmann, M; Lubin, JH; Stewart, PA; Hayes, RB; Blair, A. (2004a). Cancer mortality among workers in formaldehyde industries [Abstract]. Ann Epidemiol 14: 608. 10.1016/j.annepidem.2004.07.045.
Hauptmann, M; Lubin, JH; Stewart, PA; Hayes, RB; Blair, A. (2004b). Mortality from solid cancers among workers in formaldehyde industries. Am J Epidemiol 159: 1117–1130. 10.1093/aje/kwh174.15191929
Hauptmann, M; Stewart, PA; Lubin, JH; Beane Freeman, LE; Hornung, RW; Herrick, RF; Hoover, RN; Fraumeni, JF, Jr; Blair, A; Hayes, RB. (2009). Mortality from lymphohematopoietic malignancies and brain cancer among embalmers exposed to formaldehyde. J Natl Cancer Inst 101: 1696–1708. 10.1093/jnci/djp416.19933446
Haworth, S; Lawlor, T; Mortelmans, K; Speck, W; Zeiger, E. (1983). Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5: 3–142. 10.1002/em.2860050703.
Hawthorne, AR; Gammage, RB; Dudney, CS; Womack, DR; Morris, SA; Westley, RR; Gupta, DC. (1983). Preliminary results of a forty-home indoor air pollutant monitoring study. In ER Frederick (Ed.), Proceedings of the Air Pollution Control Association Specialty Conference: Measurement and Monitoring of Non-Criteria (TOXIC) Contaminants in Air, Chicago, IL, March 22-24, 1983 (pp. 514–526). Philadelphia, PA: Air Pollution Control Association. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE83009839.xhtml.
Hayashi, H; Kunugita, N; Arashidani, K; Fujimaki, H; Ichikawa, M. (2004). Long-term exposure to low levels of formaldehyde increases the number of tyrosine hydroxylase-immunopositive periglomerular cells in mouse main olfactory bulb. Brain Res 1007: 192–197. 10.1016/j.brainres.2003.12.052.15064152
Hayes, RB; Blair, A; Stewart, PA; Herrick, RF; Mahar, H. (1990). Mortality of U.S. embalmers and funeral directors. Am J Ind Med 18: 641–652. 10.1002/ajim.4700180603.2264563
Hayes, RB; Gerin, M; Raatgever, JW; de Bruyn, A. (1986a). Wood-related occupations, wood dust exposure, and sinonasal cancer. Am J Epidemiol 124: 569–577. 10.1093/oxfordjournals.aje.a114429.3752051
Hayes, RB; Klein, S; Suruda, A; Schulte, P; Boeniger, M; Stewart, P; Livingston, GK; Oesch, F. (1997). O6-alkylguanine DNA alkyltransferase activity in student embalmers. Am J Ind Med 31: 361–365. 10.1002/(SICI)1097-0274(199703)31:3<361::AID-AJIM13>3.0.CO;2-Z.9055960
Hayes, RB; Raatgever, JW; de Bruyn, A; Gerin, M. (1986b). Cancer of the nasal cavity and paranasal sinuses, and formaldehyde exposure. Int J Cancer 37: 487–492. 10.1002/ijc.2910370403.3957459
Hd’A, H; Casanova, M. (1994). Nasal dosimetry of formaldehyde: Modeling site specificity and the effects of preexposure. Inhal Toxicol 6 supplement: 159–175.
He, HJ; Liu, HL; Wu, J; Lu, ZS; Yan, Y; Yang, X; Li, CM. (2005). A study on the acute irritation responses and molecular mechanism of gaseous formaldehyde. In X Yang; B Zhao; R Zhao (Eds.), Indoor Air 2005: Proceedings of the 10th International Conference on Indoor Air Quality and Climate, vol 5 (pp. 3691–3695). Beijing, China: Tsinghua University Press. https://www.isiaq.org/docs/PDFs/3691.pdf.
He, JL; Jin, LF; Jin, HY. (1998). Detection of cytogenetic effects in peripheral lymphocytes of students exposed to formaldehyde with cytokinesis-blocked micronucleus assay. Biomed Environ Sci 11: 87–92.9559107
Health Canada. (2001). Priority substances list assessment report Formaldehyde. Hull, Quebec, Canada: Environment Canada and Health Canada.
Health Canada. (2006). Residential indoor air quality guideline. Formaldehyde. http://healthycanadians.gc.ca/publications/healthy-living-vie-saine/formaldehyde/alt/formaldehyde-eng.pdf.
Heck, H; Casanova-Schmitz, M; Dodd, PB; Schachter, EN; Witek, TJ; Tosun, T. (1985). Formaldehyde (CH2O) concentrations in the blood of humans and Fischer-344 rats exposed to CH2O under controlled conditions. AIHA J 46: 1–3. 10.1080/15298668591394275.
Heck, H; Casanova, M. (1987). Isotope effects and their implications for the covalent binding of inhaled [3H]- and [14C]formaldehyde in the rat nasal mucosa. Toxicol Appl Pharmacol 89: 122–134. 10.1016/0041-008X(87)90182-7.3590184
Heck, H; Casanova, M. (1999). Pharmacodynamics of formaldehyde: Applications of a model for the arrest of DNA replication by DNA-protein cross-links. Toxicol Appl Pharmacol 160: 86–100. 10.1006/taap.1999.8764.10502505
Heck, H; Chin, TY; Schmitz, MC. (1983). Distribution of [14C] formaldehyde in rats after inhalation exposure. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 26–37). Washington, DC: Hemisphere Publishing.
Heck, H; Keller, DA. (1988). Toxicology of formaldehyde. ISI Atlas of Science: Pharmacology 2: 5–9.
Heck, H; White, EL; Casanova-Schmitz, M. (1982). Determination of formaldehyde in biological tissues by gas chromatography/mass spectrometry. Biomed Mass Spectrom 9: 347–353. 10.1002/bms.1200090808.7126766
Hedberg, JJ; Höög, JO; Nilsson, JA; Xi, Z; Elfwing, A; Grafström, RC. (2000). Expression of alcohol dehydrogenase 3 in tissue and cultured cells from human oral mucosa. Am J Pathol 157: 1745–1755. 10.1016/S0002-9440(10)64811-0.11073833
Heineman, EF; Olsen, JH; Pottern, LM; Gomez, M; Raffn, E; Blair, A. (1992). Occupational risk factors for multiple myeloma among Danish men. Cancer Causes Control 3: 555–568. 10.1007/BF00052753.1420859
Hemminki, K; Kyyrönen, P; Lindbohm, ML. (1985). Spontaneous abortions and malformations in the offspring of nurses exposed to anaesthetic gases, cytostatic drugs, and other potential hazards in hospitals, based on registered information of outcome. J Epidemiol Community Health 39: 141–147. 10.1136/jech.39.2.141.3925060
Hemminki, K; Mutanen, P; Saloniemi, I; Niemi, ML; Vainio, H. (1982). Spontaneous abortions in hospital staff engaged in sterilizing instruments with chemical agents. J Occup Environ Med 285: 1461–1463.
Henry, AJ. (2008). CDC finds cause of health problems from emergency trailers. Bull Am Meteorol Soc 89: 1251–1252,1254.
Herbert, FA; Hessel, PA; Melenka, LS; Yoshida, K; Nakaza, M. (1994). Respiratory consequences of exposure to wood dust and formaldehyde of workers manufacturing oriented strand board. Arch Environ Health 49: 465–470. 10.1080/00039896.1994.9955002.7818289
Herbert, FA; Hessel, PA; Melenka, LS; Yoshida, K; Nakaza, M. (1995). Pulmonary effects of simultaneous exposures to MDI formaldehyde and wood dust on workers in an oriented strand board plant. J Occup Environ Med 37: 461–465. 10.1097/00043764-199504000-00018.7670902
Hernandez, O; Rhomberg, L; Hogan, K; Siegel-Scott, C; Lai, D; Grindstaff, G; Henry, M; Cotruvo, JA. (1994). Risk assessment of formaldehyde. J Hazard Mater 39: 161–172. 10.1016/0304-3894(94)00067-0.
Hester, SD; Benavides, GB; Yoon, L; Morgan, KT; Zou, F; Barry, W; Wolf, DC. (2003). Formaldehyde-induced gene expression in F344 rat nasal respiratory epithelium. Toxicology 187: 13–24. 10.1016/S0300-483X(03)00008-8.12679049
Hikiba, H; Watanabe, E; Barrett, JC; Tsutsui, T. (2005). Ability of fourteen chemical agents used in dental practice to induce chromosome aberrations in Syrian hamster embryo cells. J Pharmacol Sci 97: 146–152. 10.1254/jphs.fpj04044x.15665446
Hildesheim, A; Anderson, LM; Chen, CJ; Cheng, YJ; Brinton, LA; Daly, AK; Reed, CD; Chen, IH; Caporaso, NE; Hsu, MM; Chen, JY; Idle, JR; Hoover, RN; Yang, CS; Chhabra, SK. (1997). CYP2E1 genetic polymorphisms and risk of nasopharyngeal carcinoma in Taiwan. J Natl Cancer Inst 89: 1207–1212. 10.1093/jnci/89.16.1207.9274915
Hildesheim, A; Dosemeci, M; Chan, CC; Chen, CJ; Cheng, YJ; Hsu, MM; Chen, IH; Mittl, BF; Sun, B; Levine, PH; Chen, JY; Brinton, LA; Yang, CS. (2001). Occupational exposure to wood, formaldehyde, and solvents and risk of nasopharyngeal carcinoma. Cancer Epidemiol Biomarkers Prev 10: 1145–1153.11700262
Hildesheim, A; West, S; Deveyra, E; De Guzman, MF; Jurado, A; Jones, C; Imai, J; Hinuma, Y. (1992). Herbal medicine use, Epstein-Barr virus, and risk of nasopharyngeal carcinoma. Cancer Res 52: 3048–3051.1317256
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Ho, KF; Lee, SC; Tsai, WY. (2006). Carbonyl compounds in the roadside environment of Hong Kong. J Hazard Mater 133: 24–29. 10.1016/j.jhazmat.2005.09.054.16297535
Hodgson, AT; Beal, D; Mcilvaine, JER. (2002). Sources of formaldehyde, other aldehydes and terpenes in a new manufactured house. Indoor Air 12: 235–242. 10.1034/j.1600-0668.2002.01129.x.12532755
Hodgson, AT; Rudd, AF; Beal, D; Chandra, S. (2000). Volatile organic compound concentrations and emission rates in new manufactured and site-built houses. Indoor Air 10: 178–192. 10.1034/j.1600-0668.2000.010003178.x.10979199
Hofmaier, S; Comberiati, P; Matricardi, PM. (2014). Immunoglobulin G in IgE-mediated allergy and allergen-specific immunotherapy [Review]. Eur Ann Allergy Clin Immunol 46: 6–11.24702866
Hogan, SP; Mould, AW; Young, JM; Rothenberg, ME; Ramsay, AJ; Matthaei, K; Young, IG; Foster, PS. (1998). Cellular and molecular regulation of eosinophil trafficking to the lung. Immunol Cell Biol 76: 454–460. 10.1046/j.1440-1711.1998.00766.x.9797467
Holgate, ST; Samet, JM; Koren, HS; Maynard, RL. (1999). Air pollution and health. San Diego, CA: Academic Press.
Holmes, BJ; Macary, PA; Noble, A; Kemeny, DM. (1997). Antigen-specific CD8+ T cells inhibit IgE responses and interleukin-4 production by CD4+ T cells. Eur J Immunol 27: 2657–2665. 10.1002/eji.1830271027.9368623
Holmström, M; Rosén, G; Wilhelmsson, B. (1991). Symptoms, airway physiology and histology of workers exposed to medium-density fiber board. Scand J Work Environ Health 17: 409–413. 10.5271/sjweh.1685.1788535
Holmstrom, M; Rynnel-Dagoo, B; Wilhelmsson, B. (1989a). Antibody production in rats after long-term exposure to formaldehyde. Toxicol Appl Pharmacol 100: 328–333. 10.1016/0041-008X(89)90318-9.2789442
Holmström, M; Wilhelmsson, B. (1988). Respiratory symptoms and pathophysiological effects of occupational exposure to formaldehyde and wood dust. Scand J Work Environ Health 14: 306–311.3201190
Holmstrom, M; Wilhelmsson, B; Hellquist, H. (1989b). Histological changes in the nasal mucosa in rats after long-term exposure to formaldehyde and wood dust. Acta Otolaryngol 108: 274–283. 10.3109/00016488909125528.2816342
Holmstrom, M; Wilhelmsson, B; Hellquist, H; Rosen, G. (1989c). Histological changes in the nasal mucosa in persons occupationally exposed to formaldehyde alone and in combination with wood dust. Acta Otolaryngol 107: 120–129. 10.3109/00016488909127488.2929309
Holness, DL; Nethercott, JR. (1989). Health status of funeral service workers exposed to formaldehyde. Arch Environ Occup Health 44: 222–228. 10.1080/00039896.1989.9935887.
Hoogenveen, RT; Clewell, HJ; Andersen, ME; Slob, W. (1999). An alternative exact solution of the two-stage clonal growth model of cancer. Risk Anal 19: 9–14. 10.1111/j.1539-6924.1999.tb00381.x.
Hopner, T; Knappe, J. (1974). Formate determination with formate dehydrogenase. In HU Bergmeyer (Ed.), Methods of Enzymatic Analysis, 2nd Ed (pp. 1551). New York: Academic Press.
Horton, AW; Tye, R; Stemmer, KL. (1963). Experimental carcinogenesis of the lung: Inhalation of gaseous formaldehyde or an aerosol of coal tar by C3H mice. J Natl Cancer Inst 30: 31–40. 10.1093/jnci/30.1.31.13964040
Horvath, EP, Jr; Anderson, H, Jr; Pierce, WE; Hanrahan, L; Wendlick, JD. (1988). Effects of formaldehyde on the mucous membranes and lungs: A study of an industrial population. JAMA 259: 701–707. 10.1001/jama.1988.03720050037020.3336189
Hosgood, HD, III; Zhang, L; Tang, X; Vermeulen, R; Hao, Z; Shen, M, in; Qiu, C; Ge, Y; Hua, M; Ji, Z; Li, S; Xiong, J, un; Reiss, B; Liu, S; Xin, KX; Azuma, M; Xie, Y; Freeman, LB; Ruan, X; Guo, W; Galvan, N, oe; Blair, A; Li, L; Huang, H; Smith, MT; Rothman, N; Lan, Q. (2013). Occupational exposure to formaldehyde and alterations in lymphocyte subsets. Am J Ind Med 56: 252–257. 10.1002/ajim.22088.22767408
Howarth, PH; Beckett, P; Dahl, R. (2000). The effect of long-acting beta2-agonists on airway inflammation in asthmatic patients [Review]. Respir Med 94 Suppl F: S22–S25.
Hsu, NY; Lee, CC; Wang, JY; Li, YC; Chang, HW; Chen, CY; Bornehag, CG; Wu, PC; Sundell, J; Su, HJ. (2012). Predicted risk of childhood allergy, asthma and reported symptoms using measured phthalate exposure in dust and urine. Indoor Air 22: 186–199. 10.1111/j.1600-0668.2011.00753.x.21995786
Huang, C; Liu, W; Cai, J; Wang, X; Zou, Z; Sun, CJ. (2017). Household formaldehyde exposure and its associations with dwelling characteristics, lifestyle behaviours, and childhood health outcomes in Shanghai, China. Build Environ 125: 143–152. 10.1016/j.buildenv.2017.08.042.
Huang, H; Hopkins, PB. (1993). DNA interstrand cross-linking by formaldehyde - nucleotide-sequence preference and covalent structure of the predominant cross-link formed in synthetic oligonucleotides. J Am Chem Soc 115: 9402–9408. 10.1021/ja00074a005.
Huang, HF; Solomon, MS; Hopkins, PB. (1992). Formaldehyde preferentially interstrand cross-links duplex DNA through deoxyadenosine residues at the sequence 5’-d(AT). J Am Chem Soc 114: 9240–9241. 10.1021/ja00049a097.
Huang, J; Lu, Y; Zhang, B; Yang, S; Zhang, Q; Cui, H; Lu, X; Zhao, Y; Yang, X; Li, R. (2019). Antagonistic effect of epigallocatechin-3-gallate on neurotoxicity induced by formaldehyde. Toxicology 412: 29–36. 10.1016/j.tox.2018.10.022.30395894
Huber, M; Lohoff, M. (2015). Change of paradigm: CD8+ T cells as important helper for CD4+ T cells during asthma and autoimmune encephalomyelitis [Review]. 24: 8–15. 10.1007/s40629-015-0038-4.
Hulin, M; Caillaud, D; Annesi-Maesano, I. (2010). Indoor air pollution and childhood asthma: variations between urban and rural areas. Indoor Air 20: 502–514. 10.1111/j.1600-0668.2010.00673.x.20846209
Hulsmann, AR; Dejongste, JC. (1996). Modulation of airway responsiveness by the airway epithelium in humans: Putative mechanisms. Clin Exp Allergy 26: 1236–1242.8955571
Hummel, T; Livermore, A. (2002). Intranasal chemosensory function of the trigeminal nerve and aspects of its relation to olfaction [Review]. Int Arch Occup Environ Health 75: 305–313. 10.1007/s00420-002-0315-7.11981669
Hwang, G; Yoon, C; Choi, J. (2011). A case-control study: exposure assessment of VOCs and formaldehyde for asthma in children. Aerosol Air Qual Res 11: 908–914. 10.4209/aaqr.2011.05.0072.
IARC (International Agency for Research on Cancer). (1995). Wood dust and formaldehyde. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol62/index.php.
IARC (International Agency for Research on Cancer). (2006). Formaldehyde, 2-butoxyethanol and 1-tert-butoxypropan-2-ol [IARC Monograph] (pp. USD 40). (CIS/07/01141). Lyon, France. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Monographs-On-The-Identification-Of-Carcinogenic-Hazards-To-Humans/Formaldehyde-2-Butoxyethanol-And-1--Em-Tert-Em--Butoxypropan-2-ol-2006.
IARC, IAfRoC. (2006). IARC monographs on the evaluation of carcinogenic risks to humans - Formaldehyde, 2-butoxyethanol, and 1--butoxypropan-2-ol (pp. USD 40). (CIS/07/01141). International Agency for Research on Cancer (IARC).
IARC (International Agency for Research on Cancer). (2012). Formaldehyde [IARC Monograph]. In A review of human carcinogens: Chemical agents and related occupations (pp. 401–435). Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol100F/index.php.
Iarmarcovai, G; Botta, A; Orsiere, T. (2006). Number of centromeric signals in micronuclei and mechanisms of aneuploidy. Toxicol Lett 166: 1–10. 10.1016/j.toxlet.2006.05.015.16854538
Ibrahim, BS; Barioni, ED; Heluany, C; Braga, TT; Drewes, CC; Costa, SG; Saraiva Camara, NO; Poliselli Farsky, SH; Lino-Dos-Santos-Franco, A. (2016). Beneficial effects of vitamin C treatment on pregnant rats exposed to formaldehyde: Reversal of immunosuppression in the offspring. Toxicol Appl Pharmacol 300: 77–81. 10.1016/j.taap.2016.03.010.27020608
ICRP (International Commission on Radiological Protection). (1994). Human respiratory tract model for radiological protection. Ann ICRP 24.
Im, H; Oh, E; Mun, J; Khim, JY; Lee, E; Kang, HS; Kim, E; Kim, H; Won, NH; Kim, YH; Jung, WW; Sul, D. (2006). Evaluation of toxicological monitoring markers using proteomic analysis in rats exposed to formaldehyde. J Proteome Res 5: 1354–1366. 10.1021/pr050437b.16739987
Imbus, HR; Tochilin, SJ. (1988). Acute effect upon pulmonary function of low level exposure to phenol-formaldehyde-resin-coated wood. AIHA J 49: 434–437. 10.1080/15298668891380033.
Inoue, K; Nishimukai, H; Yamasawa, K. (1979). Purification and partial characterization of aldehyde dehydrogenase from human erythrocytes. Biochim Biophys Acta 569: 117–123. 10.1016/0005-2744(79)90046-9.224930
Ionescu, J; Marinescu, D; Tapu, V; Eskenasy, A. (1978). Experimental chronic obstructive lung disease: I. Bronchopulmonary changes induced in rabbits by prolonged exposure to formaldehyde. Morphol Embryol (Bucur) 24: 233–242.151223
IPCS (International Programme on Chemical Safety). (1989). Environmental Health Criteria 89: Formaldehyde [WHO EHC]. In Environmental Health Criteria Vol 89. (EHC 89). Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc89.htm.
IPCS (International Programme on Chemical Safety). (2002). Concise International Chemical Assessment Document 40: Formaldehyde. Geneva, Switzerland: World Health Organization. https://inchem.org/documents/cicads/cicads/cicad40.htm.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Isa, KNM; Hashim, Z; Jalaludin, J; Norback, D, an; Jabbar, MA; Hashim, JH. (2020a). The Impact of Exposure to Indoor Pollutants on Allergy and Lung Inflammation among School Children in Selangor, Malaysia: An Evaluation Using Factor Analysis. Aerosol Air Qual Res 20: 2371–2383. 10.4209/aaqr.2020.03.0128.
Isa, KNM; Hashim, Z; Jalaludin, J; Than, LTL; Hashim, JH. (2020b). The effects of indoor pollutants exposure on allergy and lung inflammation: An activation state of neutrophils and eosinophils in sputum. Int J Environ Res Public Health 17: 5413. 10.3390/ijerph17155413.32731346
Ishidate, M, Jr; Sofuni, T; Yoshikawa, K. (1981). Chromosomal aberration tests in vitro as a primary screening tool for environmental mutagens and/or carcinogens. In N Inui; T Kuroki; MA Yamada; C Heidelberger (Eds.), Mutation, promotion and transformation in vitro (pp. 95–108). Tokyo, Japan: Japan Scientific Societies Press.
Ito, K; Sakamoto, T; Hayashi, Y; Morishita, M; Shibata, E; Sakai, K; Takeuchi, Y; Torii, S. (1996). Role of tachykinin and bradykinin receptors and mast cells in gaseous formaldehyde-induced airway microvascular leakage in rats. Eur J Pharmacol 307: 291–298. 10.1016/0014-2999(96)00285-3.8836617
Jacobsen, EA; Lee, NA; Lee, JJ. (2014). Re-defining the unique roles for eosinophils in allergic respiratory inflammation [Review]. Clin Exp Allergy 44: 1119–1136. 10.1111/cea.12358.24961290
Jaeger, RJ; Gearhart, JM. (1982). Respiratory and metabolic response of rats and mice to formalin vapor. Toxicology 25: 299–309. 10.1016/0300-483X(82)90108-1.6818719
Jakab, GJ. (1992). Relationship between carbon black particulate-bound formaldehyde, pulmonary antibacterial defenses, and alveolar macrophage phagocytosis. Inhal Toxicol 4: 325–342. 10.3109/08958379209145312.
Jakab, MG; Klupp, T; Besenyei, K; Biro, A; Major, J; Tompa, A. (2010). Formaldehyde-induced chromosomal aberrations and apoptosis in peripheral blood lymphocytes of personnel working in pathology departments. Mutat Res 698: 11–17. 10.1016/j.mrgentox.2010.02.015.20193773
Jakobsson, K; Mikoczy, Z; Skerfving, S. (1997). Deaths and tumours among workers grinding stainless steel: a follow up. Occup Environ Med 54: 825–829. 10.1136/oem.54.11.825.9538356
Jantunen, K; Maki-Paakkanen, J; Norppa, H. (1986). Induction of chromosome aberrations by styrene and vinylacetate in cultured human lymphocytes: Dependence on erythrocytes. Mutat Res 159: 109–116. 10.1016/0027-5107(86)90119-3.3941660
Jensen, DE; Belka, GK; Du Bois, GC. (1998). S-Nitrosoglutathione is a substrate for rat alcohol dehydrogenase class III isoenzyme. Biochem J 331: 659–668. 10.1042/bj3310659.9531510
Jensen, KA; Kirk, I; Kølmark, G; Westergaard, M. (1951). Chemically induced mutations in Neurospora. Cold Spring Harb Symp Quant Biol 16: 245–261. 10.1101/SQB.1951.016.01.020.14942743
Ji, Z; Li, X; Fromowitz, M; Mutter-Rottmayer, E; Tung, J; Smith, MT; Zhang, L. (2014). Formaldehyde induces micronuclei in mouse erythropoietic cells and suppresses the expansion of human erythroid progenitor cells. Toxicol Lett 224: 233–239. 10.1016/j.toxlet.2013.10.028.24188930
Jia, X; Jia, Q; Zhang, Z; Gao, W; Zhang, X; Niu, Y; Meng, T; Feng, B; Duan, H; Ye, M; Dai, Y; Jia, Z; Zheng, Y. (2014). Effects of formaldehyde on lymphocyte subsets and cytokines in the peripheral blood of exposed workers. PLoS ONE 9: e104069. 10.1371/journal.pone.0104069.25157974
Jiang, J; Zhou, CF; Gao, S; Tian, Y; Wang, C; Wang, L, i; Gu, HF; Tang, XQ. (2015). BDNF-TrkB Pathway Mediates Neuroprotection of Hydrogen Sulfide against Formaldehyde-Induced Toxicity to PC12 Cells. PLoS ONE 10: e0119478. 10.1371/journal.pone.0119478.25749582
Jiang, S; Yu, L; Cheng, J; Leng, S; Dai, Y; Zhang, Y; Niu, Y; Yan, H; Qu, W; Zhang, C; Zhang, K; Yang, R; Zhou, L; Zheng, Y. (2010). Genomic damages in peripheral blood lymphocytes and association with polymorphisms of three glutathione S-transferases in workers exposed to formaldehyde. Mutat Res 695: 9–15. 10.1016/j.mrgentox.2009.09.011.19818869
Jin, L; Lynch, J; Richardson, A; Lorkiewicz, P; Srivastava, S; Theis, W; Shirk, G; Hand, A; Bhatnagar, A; Srivastava, S; Conklin, DJ. (2021). Electronic Cigarette Solvents, Pulmonary Irritation and Endothelial Dysfunction:Role of Acetaldehyde and Formaldehyde. Am J Physiol Heart Circ Physiol 320: H1510–H1525. 10.1152/ajpheart.00878.2020.33543686
Jinot, J; Beane-Freeman, L. (2014). Personal communication Jennifer Jinot and Laura Beane-Freeman. Available online at (accessed
John, EM; Savitz, DA; Shy, CM. (1994). Spontaneous abortions among cosmetologists. Epidemiology 5: 147–155. 10.1097/00001648-199403000-00004.8172989
Johnsen, RC; Baillie, DL. (1988). Formaldehyde mutagenesis of the eT1 balanced region in Caenorhabditis elegans: dose-response curve and the analysis of mutational events. Mutat Res 201: 137–147. 10.1016/0027-5107(88)90120-0.3419443
Joos, GF; Germonpre, PF; Pauwels, RA. (2000). Role of tachykinins in asthma [Review]. Allergy 55: 321–337. 10.1034/j.1398-9995.2000.00112.x.10782516
Joos, GF; Germonpre, PR; Kips, JC; Peleman, RA; Pauwels, RA. (1994). SENSORY NEUROPEPTIDES AND THE HUMAN LOWER AIRWAYS - PRESENT STATE AND FUTURE-DIRECTIONS. Eur Respir J 7: 1161–1171.7925887
Joos, GF; Kips, JC; Peleman, RA; Pauwels, RA. (1995). TACHYKININ ANTAGONISTS AND THE AIRWAYS. Arch Int Pharmacodyn Ther 329: 205–219.7543746
Juarez, E; Chambwe, N; Tang, W; Mitchell, AD; Owen, N; Kumari, A; Monnat, RJ; Mccullough, AK. (2018). An RNAi screen in human cell lines reveals conserved DNA damage repair pathways that mitigate formaldehyde sensitivity. DNA Repair 72: 1–9. 10.1016/j.dnarep.2018.10.002.30389308
Jude, J; Koziol-White, C; Scala, J; Yoo, E; Jester, W; Maute, C; Dalton, P; Panettieri, R. (2016). Formaldehyde Induces Rho-associated Kinase Activity to Evoke Airway Hyperresponsiveness. Am J Respir Cell Mol Biol 55: 542–553. 10.1165/rcmb.2015-0254OC.27149505
Jung, R; Engelhart, G; Herbolt, B; Jäckh, R; Müller, W. (1992). Collaborative study of mutagenicity with Salmonella typhimurium TA102. Mutat Res 278: 265–270. 10.1016/S0165-1218(10)80006-0.1373863
Jung, W; Kim, E; Lee, E; Yun, H; Ju, H; Jeong, M; Hwang, K; Sul, D; Kang, H. (2007). Formaldehyde exposure induces airway inflammation by increasing eosinophil infiltrations through the regulation of reactive oxygen species production. Environ Toxicol Pharmacol 24: 174–182. 10.1016/j.etap.2007.05.001.21783807
Kallen, RG; Jencks, WP. (1966a). The dissociation constants of tetrahydrofolic acid. J Biol Chem 241: 5845–5850.5954362
Kallen, RG; Jencks, WP. (1966b). The mechanism of the condensation of formaldehyde with tetrahydrofolic acid. J Biol Chem 241: 5851–5863.5954363
Kamata, E; Nakadate, M; Ogawa, Y; Kaneko, T; Kurokawa, Y; Yukawa, M. (1996a). Acute inhalation toxicity study of formaldehyde in rats: Effect of vapor on the pulmonary surfactant. Oyo Yakuri 51: 33–37.
Kamata, E; Nakadate, M; Uchida, O; Ogawa, Y; Kaneko, T; Kurokawa, Y. (1996b). Effects of formaldehyde vapor on the nasal cavity and lungs of F-344 rats. J Environ Pathol Toxicol Oncol 15: 1–8.9037259
Kamata, E; Nakadate, M; Uchida, O; Ogawa, Y; Suzuki, S; Kaneko, T; Saito, M; Kurokawa, Y. (1997). Results of a 28-month chronic inhalation toxicity study of formaldehyde in male Fisher-344 rats. J Toxicol Sci 22: 239–254.
Kane, LE; Alarie, Y. (1977). Sensory irritation to formaldehyde and acrolein during single and repeated exposures in mice. Am Ind Hyg Assoc J 38: 509–522. 10.1080/0002889778507665.562615
Kane, LE; Barrow, CS; Alarie, Y. (1979). A short-term test to predict acceptable levels of exposure to airborne sensory irritants. Am Ind Hyg Assoc J 40: 207–229. 10.1080/15298667991429516.495461
Kang, J; Duan, J; Song, J; Luo, C; Liu, H; Li, B; Yang, X; Yu, W; Chen, M. (2018). Exposure to a combination of formaldehyde and DINP aggravated asthma-like pathology through oxidative stress and NF-κB activation. Toxicology 404–405: 49–58. 10.1016/j.tox.2018.05.006.
Kang, S, ukYun; North, J, in; Gaytán, J; Romero, W, oo; De La Rosa, VY; Loguinov, A; Smith, MT; Zhang, L; Vulpe, CD. (2016). Functional Toxicogenomic Profiling Expands Insight into Modulators of Formaldehyde Toxicity in Yeast. Front Genet 7: 200. 10.3389/fgene.2016.00200.27909446
Kaplan, EL; Meier, P. (1958). Nonparametric estimation from incomplete observations. J Am Stat Assoc 53: 457–481. 10.1080/01621459.1958.10501452.
Kaplan, WD. (1948). Formaldehyde as a mutagen in Drosophila. Science 108: 43. 10.1126/science.108.2793.43.17739233
Kastner, PE; Le Calvé, S; Zheng, W; Casset, A; Pons, F. (2013). A dynamic system for single and repeated exposure of airway epithelial cells to gaseous pollutants. Toxicol In Vitro 27: 632–640. 10.1016/j.tiv.2012.11.011.23168489
Katsnelson, BA; Degtyareva, TD; Privalova, LI; Minigaliyeva, IA; Slyshkina, TV; Ryzhov, VV; Beresneva, OY, u. (2013). Attenuation of subchronic formaldehyde inhalation toxicity with oral administration of glutamate, glycine and methionine. Toxicol Lett 220: 181–186. 10.1016/j.toxlet.2013.04.024.23660335
Kauppinen, T; Teschke, K; Savela, A; Kogevinas, M; Boffetta, P. (1997). International data base of exposure measurements in the pulp, paper and paper product industries. Int Arch Occup Environ Health 70: 119–127. 10.1007/s004200050195.9253640
Keller, DA; Heck, H; Randall, HW; Morgan, KT. (1990). Histochemical localization of formaldehyde dehydrogenase in the rat. Toxicol Appl Pharmacol 106: 311–326. 10.1016/0041-008x(90)90250-x.2256119
Kelly, TJ; Smith, DL; Satola, J. (1999). Emission rates of formaldehyde from materials and consumer products found in California homes. Environ Sci Technol 33: 81–88. 10.1021/es980592%2B.
Kennedy, G; Slaich, PK; Golding, BT; Watson, WP. (1996). Structure and mechanism of formation of a new adduct from formaldehyde and guanosine. Chem Biol Interact 102: 93–100. 10.1016/S0009-2797(96)03737-4.8950224
Kepler, GM; Richardson, RB; Morgan, KT; Kimbell, JS. (1998). Computer simulation of inspiratory nasal airflow and inhaled gas uptake in a rhesus monkey. Toxicol Appl Pharmacol 150: 1–11. 10.1006/taap.1997.8350.9630447
Kerfoot, EJ; Mooney, TF. (1975). Formaldehyde and paraformaldehyde study in funeral homes. Am Ind Hyg Assoc J 36: 533–537. 10.1080/0002889758507286.1229899
Kerns, WD; Pavkov, KL; Donofrio, DJ; Gralla, EJ; Swenberg, JA. (1983). Carcinogenicity of formaldehyde in rats and mice after long-term inhalation exposure. Cancer Res 43: 4382–4392.6871871
Khaliq, F; Tripathi, P. (2009). Acute effects of formalin on pulmonary functions in gross anatomy laboratory. Indian J Physiol Pharmacol 53: 93–96.19810583
Khamgaonkar, MB; Fulare, MB. (1991). Pulmonary effects of formaldehyde exposure--an environmental-epidemiological study. Indian J Chest Dis Allied Sci 33: 9–13.1791022
Khan, AH. (1967). The induction of crossing over in the absence of mutation. Sind University Science Research Journal 3: 103–106.
Kiernan, JA. (2000). Formaldehyde, formalin, paraformaldehyde and glutaraldehyde: What they are and what they do. Microsc Today 00–1: 8–12.
Kilburn, KH. (2000). Indoor air effects after building renovation and in manufactured homes. Am J Med Sci 320: 249–254. 10.1097/00000441-200010000-00005.11061350
Kilburn, KH; Mckenzie, WN. (1978). Leukocyte recruitment to airways by aldehyde-carbon combinations that mimic cigarette smoke. Lab Invest 38: 134–142.564424
Kilburn, KH; Seidman, BC; Warshaw, R. (1985a). Neurobehavioral and respiratory symptoms of formaldehyde and xylene exposure in histology technicians. Arch Environ Occup Health 40: 229–233. 10.1080/00039896.1985.10545924.
Kilburn, KH; Warshaw, R; Boylen, CT; Johnson, SJ; Seidman, B; Sinclair, R; Takaro, T. (1985b). Pulmonary and neurobehavioral effects of formaldehyde exposure. Arch Environ Health 40: 254–260. 10.1080/00039896.1985.10545928.4062359
Kilburn, KH; Warshaw, R; Thornton, JC. (1987). Formaldehyde impairs memory, equilibrium, and dexterity in histology technicians: Effects which persist for days after exposure. Arch Environ Occup Health 42: 117–120. 10.1080/00039896.1987.9935806.
Kilburn, KH; Warshaw, R; Thornton, JC. (1989a). Pulmonary function in histology technicians compared with women from Michigan: effects of chronic low dose formaldehyde on a national sample of women. Br J Ind Med 46: 468–472. 10.1136/oem.46.7.468.2765419
Kilburn, KH; Warshaw, R; Thornton, JC; Husmark, I. (1989b). An examination of factors that could affect choice reaction time in histology technicians. Am J Ind Med 15: 679–686. 10.1002/ajim.4700150607.2750743
Kilburn, KH; Warshaw, RH. (1992). Neurobehavioral effects of formaldehyde and solvents on histology technicians: Repeated testing across time. Environ Res 58: 134–146. 10.1016/S0013-9351(05)80210-5.1511669
Kim, EM; Lee, HY; Lee, EH; Lee, KM; Park, M; Ji, KY; Jang, JH; Jeong, YH; Lee, KH; Yoon, IJ; Kim, SM; Jeong, MJ; Kim, KD; Kang, HS. (2013a). Formaldehyde exposure impairs the function and differentiation of NK cells. Toxicol Lett 223: 154–161. 10.1016/j.toxlet.2013.09.008.24060340
Kim, H; Kim, YD; Cho, SH. (1999). Formaldehyde exposure levels and serum antibodies to formaldehyde-human serum albumin of Korean medical students. Arch Environ Health 54: 115–118. 10.1080/00039899909602245.10094289
Kim, HJ; Kim, CH; Kim, MJ; Ryu, JH; Seong, SY; Kim, S; Lim, SJ; Holtzman, MJ; Yoon, JH. (2015a). The Induction of Pattern-Recognition Receptor Expression against Influenza A Virus through Duox2-Derived Reactive Oxygen Species in Nasal Mucosa. Am J Respir Cell Mol Biol 53: 525–535. 10.1165/rcmb.2014-0334OC.25751630
Kim, JL; Elfman, L; Wieslander, G; Ferm, M; Torén, K; Norbäck, D. (2011). Respiratory health among Korean pupils in relation to home, school and outdoor environment. J Korean Med Sci 26: 166–173. 10.3346/jkms.2011.26.2.166.21286005
Kim, JY; Jeong, MS; Park, KY; Seo, SJ. (2013b). Aggravation of atopic dermatitis-like symptoms by consecutive low concentration of formaldehyde exposure in NC/Nga mice [Letter]. Exp Dermatol 22: 219–221. 10.1111/exd.12092.23387407
Kim, SM; Hwang, KA; Choi, DW; Choi, KC. (2018). The cigarette smoke components induced the cell proliferation and epithelial to mesenchymal transition via production of reactive oxygen species in endometrial adenocarcinoma cells. Food Chem Toxicol 121: 657–665. 10.1016/j.fct.2018.09.023.30236600
Kim, Y; Jekarl, DW; Kim, J; Kwon, A; Choi, H; Lee, S; Kim, YJ; Kim, HJ; Kim, Y; Oh, IH; Kim, M. (2015b). Genetic and epigenetic alterations of bone marrow stromal cells in myelodysplastic syndrome and acute myeloid leukemia patients. Stem Cell Research 14: 177–184. 10.1016/j.scr.2015.01.004.25665922
Kimbell, JS; Godo, MN; Gross, EA; Joyner, DR; Richardson, RB; Morgan, KT. (1997a). Computer simulation of inspiratory airflow in all regions of the F344 rat nasal passages. Toxicol Appl Pharmacol 145: 388–398. 10.1006/taap.1997.8206.9266813
Kimbell, JS; Gross, EA; Joyner, DR; Godo, MN; Morgan, KT. (1993). Application of computational fluid dynamics to regional dosimetry of inhaled chemicals in the upper respiratory tract of the rat. Toxicol Appl Pharmacol 121: 253–263. 10.1006/taap.1993.1152.8346542
Kimbell, JS; Gross, EA; Richardson, RB; Conolly, RB; Morgan, KT. (1997b). Correlation of regional formaldehyde flux predictions with the distribution of formaldehyde-induced squamous metaplasia in F344 rat nasal passages. Mutat Res 380: 143–154. 10.1016/S0027-5107(97)00132-2.9385395
Kimbell, JS; Overton, JH; Subramaniam, RP; Schlosser, PM; Morgan, KT; Conolly, RB; Miller, FJ. (2001a). Dosimetry modeling of inhaled formaldehyde: Binning nasal flux predictions for quantitative risk assessment. Toxicol Sci 64: 111–121.11606807
Kimbell, JS; Subramaniam, RP. (2001). Use of computational fluid dynamics models for dosimetry of inhaled gases in the nasal passages [Review]. Inhal Toxicol 13: 325–334. 10.1080/08958370120442.11295865
Kimbell, JS; Subramaniam, RP; Gross, EA; Schlosser, PM; Morgan, KT. (2001b). Dosimetry modeling of inhaled formaldehyde: comparisons of local flux predictions in the rat, monkey, and human nasal passages. Toxicol Sci 64: 100–110.11606806
Kimura, R; Kimoto, I; Takeda, M; Miyake, M; Sakamoto, T. (2010). Alteration in airway microvascular leakage induced by sensorineural stimulation in rats exposed to inhaled formaldehyde. Toxicol Lett 199: 254–260. 10.1016/j.toxlet.2010.09.007.20849939
Kita, H; Oomichi, S. (1974). Effect of air pollutants on ciliary activity of respiratory tract. Bull Tokyo Med Dent Univ 21: 327–343.4615842
Kita, T; Fujimura, M; Myou, S; Ishiura, Y; Abo, M; Katayama, N; Nishitsuji, M; Yoshimi, Y; Nomura, S; Oribe, Y; Nakao, S. (2003). Potentiation of allergic bronchoconstriction by repeated exposure to formaldehyde in guinea-pigs in vivo. Clin Exp Allergy 33: 1747–1753. 10.1111/j.1365-2222.2003.01826.x.14656365
Kitaev, EM; Savchenko, ON; Lovchikov, VA; Altukhov, VV; Vishnyakov, YS. (1984). Razvitie zarodyshey i nekotorye pokazateli reproductivnoy funktsii u krys posle ingalyatsionnogo vozdeystviya formal’degida do oplodotvoreniya [Akush Ginekol 10: 49–52.
Kitaeva, L; Kitaev, E; Pimenova, M. (1990). Cytopathic and cytogenetic effects of chronic inhalation of formaldehyde on the female rat’s germ and marrow cells. Tsitologiia 32: 1212–1216.2103083
Kitaeva, LV; Mikheeva, EA; Shelomova, LF; Shvartsman, P. (1996). [Genotoxic effect of formaldehyde in somatic human cells in vivo]. Genetika 32: 1287–1290.9026467
Klein, MD; Sinha, BK; Subramaniam, RP. (2011). Statistical inferences from formaldehyde DNA-protein cross-link data: improving methods for characterization of uncertainty. J Biopharm Stat 21: 42–55. 10.1080/10543400903531601.21191853
Klein, S; Oesch, F. (1990). A new assay for O6-alkylguanine-DNA-alkyltransferase to determine DNA repair capacities using lambda-phage DNA as substrate. Carcinogenesis 11: 1771–1774. 10.1093/carcin/11.10.1771.2145087
Kleinnijenhuis, AJ; Staal, YC; Duistermaat, E; Engel, R; Woutersen, RA. (2013). The determination of exogenous formaldehyde in blood of rats during and after inhalation exposure. Food Chem Toxicol 52: 105–112. 10.1016/j.fct.2012.11.008.23159914
Kligerman, AD; Phelps, MC; Erexson, GL. (1984). Cytogenetic analysis of lymphocytes from rats following formaldehyde inhalation. Toxicol Lett 21: 241–246. 10.1016/0378-4274(84)90079-1.6740713
Knudsen, TB; Thomsen, SF; Nolte, H; Backer, V. (2009). A population-based clinical study of allergic and non-allergic asthma. J Asthma 46: 91–94. 10.1080/02770900802524657.19191145
Kölmark, G; Westergaard, M. (1953). Further studies on chemically induced reversions at the adenine locus of Neurospora. Hereditas 39: 209–224.
Kopf, M; Le Gros, G; Bachmann, M; Lamers, MC; Bluethmann, H; Köhler, G. (1993). Disruption of the murine IL-4 gene blocks Th2 cytokine responses. Nature 362: 245–248. 10.1038/362245a0.8384701
Korhonen, K; Liukkonen, T; Ahrens, W; Astrakianakis, G; Boffetta, P; Burdorf, A; Heederik, D; Kauppinen, T; Kogevinas, M; Osvoll, P; Rix, BA; Saalo, A; Sunyer, J; Szadkowska-Stanczyk, I; Teschke, K; Westberg, H; Widerkiewicz, K. (2004). Occupational exposure to chemical agents in the paper industry. Int Arch Occup Environ Health 77: 451–460. 10.1007/s00420-004-0530-5.15368059
Koya, T; Miyahara, N; Takeda, K; Matsubara, S; Matsuda, H; Swasey, C; Balhorn, A; Dakhama, A; Gelfand, EW. (2007). CD8+ T cell-mediated airway hyperresponsiveness and inflammation is dependent on CD4+IL-4+ T cells. J Immunol 179: 2787–2796. 10.4049/jimmunol.179.5.2787.17709492
Krakowiak, A; Górski, P; Pazdrak, K; Ruta, U. (1998). Airway response to formaldehyde inhalation in asthmatic subjects with suspected respiratory formaldehyde sensitization. Am J Ind Med 33: 274–281. 10.1002/(SICI)1097-0274(199803)33:3<274::AID-AJIM9>3.0.CO;2-W.9481426
Kraneveld, AD; Nijkamp, FP. (2001). Tachykinins and neuro-immune interactions in asthma [Review]. Int Immunopharmacol 1: 1629–1650. 10.1016/S1567-5769(01)00099-6.11562057
Kraneveld, AD; van der Kleij, HP; Kool, M; van Houwelingen, AH; Weitenberg, AC; Redegeld, FA; Nijkamp, FP. (2002). Key role for mast cells in nonatopic asthma. J Immunol 169: 2044–2053. 10.4049/jimmunol.169.4.2044.12165531
Krewski, D; Crump, KS; Farmer, J; Gaylor, DW; Howe, R; Portier, C; Salsburg, D; Sielken, RL; Van Ryzin, J. (1983). A comparison of statistical methods for low dose extrapolation utilizing time-to-tumour data. Fundam Appl Toxicol 3: 140–160. 10.1016/S0272-0590(83)80075-X.6884628
Kriebel, D; Myers, D; Cheng, M; Woskie, S; Cocanour, B. (2001). Short-term effects of formaldehyde on peak expiratory flow and irritant symptoms. Arch Environ Health 56: 11–18. 10.1080/00039890109604049.11256851
Kriebel, D; Sama, SR; Cocanour, B. (1993). Reversible pulmonary responses to formaldehyde. A study of clinical anatomy students. Am Rev Respir Dis 148: 1509–1515. 10.1164/ajrccm/148.6_Pt_1.1509.8256892
Krieger, NR; Megill, JR; Sterling, P. (1983). Granule cells in the rat olfactory tubercle accumulate 3H-gamma-aminobutyric acid. J Comp Neurol 215: 465–471. 10.1002/cne.902150410.6134758
Krzyzanowski, M; Bateson, T. (2023). Correspondence with Dr. Krzyzanowski seeking additional detail regarding HERO ID: 27351 (Krzyzanowski et al., 1990). Available online at (accessed
Krzyzanowski, M; Quackenboss, JJ; Lebowitz, MD. (1990). Chronic respiratory effects of indoor formaldehyde exposure. Environ Res 52: 117–125. 10.1016/S0013-9351(05)80247-6.2394203
Kuehner, S; Holzmann, K; Speit, G. (2013). Characterization of formaldehyde’s genotoxic mode of action by gene expression analysis in TK6 cells. Arch Toxicol 87: 1999–2012. 10.1007/s00204-013-1060-2.23649840
Kuehner, S; Schlaier, M; Schwarz, K; Speit, G. (2012). Analysis of leukemia-specific aneuploidies in cultured myeloid progenitor cells in the absence and presence of formaldehyde exposure. Toxicol Sci 128: 72–78. 10.1093/toxsci/kfs126.22472192
Kulle, TJ. (1993). Acute odor and irritation response in healthy nonsmokers with formaldehyde exposure. Inhal Toxicol 5: 323–332. 10.3109/08958379308998389.
Kulle, TJ; Cooper, GP. (1975). Effects of formaldehyde and ozone on the trigeminal nasal sensory system. Arch Environ Occup Health 30: 237–243.
Kulle, TJ; Sauder, LR; Hebel, JR; Green, DJ; Chatham, MD. (1987). Formaldehyde dose-response in healthy nonsmokers. J Air Pollut Control Assoc 37: 919–924. 10.1080/08940630.1987.10466285.
Kum, C; Kiral, F; Sekkin, S; Seyrek, K; Boyacioglu, M. (2007a). Effects of xylene and formaldehyde inhalations on oxidative stress in adult and developing rats livers. Exp Anim 56: 35–42. 10.1538/expanim.56.35.17283889
Kum, C; Sekkin, S; Kiral, F; Akar, F. (2007b). Effects of xylene and formaldehyde inhalations on renal oxidative stress and some serum biochemical parameters in rats. Toxicol Ind Health 23: 115–120. 10.1177/0748233707078218.18203563
Kumari, A; Lim, YX; Newell, AH; Olson, SB; Mccullough, AK. (2012). Formaldehyde-induced genome instability is suppressed by an XPF-dependent pathway. DNA Repair 11: 236–246. 10.1016/j.dnarep.2011.11.001.22186232
Kunkler, PE; Ballard, CJ; Oxford, GS; Hurley, JH. (2011). TRPA1 receptors mediate environmental irritant-induced meningeal vasodilatation. Pain 152: 38–44. 10.1016/j.pain.2010.08.021.21075522
Kuo, HW; Jian, GJ; Chen, CL; Liu, CS; Lai, JS. (1997). White blood cell count as an indicator of formaldehyde exposure. Bull Environ Contam Toxicol 59: 261–267. 10.1007/s001289900473.9211697
Kuper, CF; van Oostrum, L; Ma-Hock, L; Durrer, S; Woutersen, RA. (2011). Hyperplasia of the lymphoepithelium of NALT in rats but not in mice upon 28-day exposure to 15 ppm formaldehyde vapor. Exp Toxicol Pathol 63: 25–32. 10.1016/j.etp.2009.09.004.19783130
Kurttio, P; Norppa, H; Jarventaus, H; Sorsa, M; Kalliokoski, P. (1993). Chromosome aberrations in peripheral lymphocytes of workers employed in the plywood industry. Scand J Work Environ Health 19: 132–134. 10.5271/sjweh.1495.
Kushch, I; Schwarz, K; Schwentner, L; Baumann, B; Dzien, A; Schmid, A; Unterkofler, K; Gastl, G; Španel, P; Smith, D; Amann, A. (2008). Compounds enhanced in a mass spectrometric profile of smokers’ exhaled breath versus non-smokers as determined in a pilot study using PTR-MS. J Breath Res 2: 026002. 10.1088/1752-7155/2/2/026002.21383443
Kuykendall, JR; Bogdanffy, MS. (1992). Efficiency of DNA-histone crosslinking induced by saturated and unsaturated aldehydes in vitro. DNA Repair 283: 131–136. 10.1016/0165-7992(92)90145-8.
Ladeira, C; Viegas, S; Carolino, E; Gomes, MC; Brito, M. (2013). The influence of genetic polymorphisms in XRCC3 and ADH5 genes on the frequency of genotoxicity biomarkers in workers exposed to formaldehyde. Environ Mol Mutagen 54: 213–221. 10.1002/em.21755.23355119
Ladeira, C; Viegas, S; Carolino, E; Prista, J; Gomes, MC; Brito, M. (2011). Genotoxicity biomarkers in occupational exposure to formaldehyde--the case of histopathology laboratories. Mutat Res 721: 15–20. 10.1016/j.mrgentox.2010.11.015.21256246
Laforest, L; Luce, D; Goldberg, P; Bégin, D; Gérin, M; Demers, PA; Brugère, J; Leclerc, A. (2000). Laryngeal and hypopharyngeal cancers and occupational exposure to formaldehyde and various dusts: A case-control study in France. Occup Environ Med 57: 767–773. 10.1136/oem.57.11.767.11024201
Lai, Y; Yu, R; Hartwell, HJ; Moeller, BC; Bodnar, WM; Swenberg, JA. (2016). Measurement of Endogenous versus Exogenous Formaldehyde-Induced DNA-Protein Crosslinks in Animal Tissues by Stable Isotope Labeling and Ultrasensitive Mass Spectrometry. Cancer Res 76: 2652–2661. 10.1158/0008-5472.CAN-15-2527.26984759
Lajoie, P; Aubin, D; Gingras, V; Daigneault, P; Ducharme, F; Gauvin, FD; Fugler, D; Leclerc, JM; Won, D; Won, D; Courteau, M; Gingras, S; Héroux, MÈ; Yang, W; Schleibinger, H. (2014). The ivaire project - a randomized controlled study of the impact of ventilation on indoor air quality and the respiratory symptoms of asthmatic children in single family homes. Indoor Air 25: 582–597. 10.1111/ina.12181.
Lam, CW; Casanova, M; Heck, H. (1985). Depletion of nasal mucosal glutathione by acrolein and enhancement of formaldehyde-induced DNA-protein cross-linking by simultaneous exposure to acrolein. Arch Toxicol 58: 67–71. 10.1007/bf00348311.4091658
Lamb, B; Westberg, H; Bryant, P; Dean, J; Mullins, S. (1985). Air infiltration rates in pre- and post-weatherized houses. J Air Pollut Control Assoc 35: 545–551. 10.1080/00022470.1985.10465931.
Lambrecht, BN; Hammad, H. (2012). The airway epithelium in asthma. Nat Med 18: 684–692. 10.1038/nm.2737.22561832
Lan, Q; Smith, MT; Tang, X; Guo, W; Vermeulen, R; Ji, Z; Hu, W; Hubbard, AE; Min, S; Mchale, CM; Qiu, C; Liu, S; Reiss, B; Beane Freeman, L; Blair, A; Ge, Y; Xiong, J; Li, L; Rappaport, SM; Huang, H; Rothman, N; Zhang, L. (2015). Chromosome-wide aneuploidy study (CWAS) of cultured circulating myeloid progenitor cells from workers occupationally exposed to formaldehyde. Carcinogenesis 36: 160–167. 10.1093/carcin/bgu229.25391402
Lang, I; Bruckner, T; Triebig, G. (2008). Formaldehyde and chemosensory irritation in humans: A controlled human exposure study. Regul Toxicol Pharmacol 50: 23–36. 10.1016/j.yrtph.2007.08.012.17942205
Larsen, ST; Wolkoff, P; Hammer, M; Kofoed-Sørensen, V; Clausen, PA; Nielsen, GD. (2013). Acute airway effects of airborne formaldehyde in sensitized and non-sensitized mice housed in a dry or humid environment. Toxicol Appl Pharmacol 268: 294–299. 10.1016/j.taap.2013.02.006.23462310
Lazenby, V; Hinwood, A; Callan, A; Franklin, P. (2012). Formaldehyde personal exposure measurements and time weighted exposure estimates in children. Chemosphere 88: 966–973. 10.1016/j.chemosphere.2012.03.029.22516208
Lazutka, JR; Lekevicius, R; Dedonyte, V; Maciuleviciute-Gervers, L; Mierauskiene, J; Rudaitiene, S; Slapsyte, G. (1999). Chromosomal aberrations and sister-chromatid exchanges in Lithuanian populations: Effects of occupational and environmental exposures. Mutat Res Genet Toxicol Environ Mutagen 445: 225–239. 10.1016/S1383-5718(99)00128-X.
Le Curieux, F; Marzin, D; Erb, F. (1993). Comparison of three short-term assays: Results on seven chemicals. Potential contribution to the control of water genotoxicity. Mutat Res 319: 223–236. 10.1016/0165-1218(93)90082-O.7694144
Leal, MP; Brochetti, RA; Ignácio, A; Câmara, NOS; da Palma, RK; de Oliveira, LVF; de Fátima Teixeira da Silva, D; Lino-Dos-Santos-Franco, A. (2018). Effects of formaldehyde exposure on the development of pulmonary fibrosis induced by bleomycin in mice. Toxicol Rep 5: 512–520. 10.1016/j.toxrep.2018.03.016.29854623
Leclerc, A; Martinez Cortes, M; Gérin, M; Luce, D; Brugère, J. (1994). Sinonasal cancer and wood dust exposure: Results from a case-control study. Am J Epidemiol 140: 340–349. 10.1093/oxfordjournals.aje.a117256.8059769
Lee, HK; Alarie, Y; Karol, MH. (1984). Induction of formaldehyde sensitivity in guinea pigs. Toxicol Appl Pharmacol 75: 147–155. 10.1016/0041-008X(84)90085-1.6464018
Leikauf, GD. (1992). Mechanisms of aldehyde-induced bronchial reactivity: Role of airway epithelium (pp. 1–35). (Research Report Number 49). Boston, MA: Health Effects Institute.
Lemus, R; Abdelghani, AA; Akers, TG; Horner, WE. (1998). Potential health risks from exposure to indoor formaldehyde. Rev Environ Health 13: 91–98.9718624
Leng, J; Liu, CW; Hartwell, HJ; Yu, R; Lai, Y; Bodnar, WM; Lu, K; Swenberg, JA. (2019). Evaluation of inhaled low-dose formaldehyde-induced DNA adducts and DNA-protein cross-links by liquid chromatography-tandem mass spectrometry. Arch Toxicol 93: 763–773. 10.1007/s00204-019-02393-x.30701286
Levandowski, RA; Ou, DW; Jackson, GG. (1986). Acute-phase decrease of T lymphocyte subsets in rhinovirus infection. J Infect Dis 153: 743–748. 10.1093/infdis/153.4.743.2936833
Levine, RJ; Andjelkovich, DA; Shaw, LK. (1984a). The mortality of Ontario (Canada) undertakers and a review of a formaldehyde-related mortality studies. J Occup Med 26: 740–746.6491780
Levine, RJ; Andjelkovich, DA; Shaw, LK. (1984b). The mortality of Ontario undertakers and a review of formaldehyde-related mortality studies [Review]. J Occup Environ Med 26: 740–746. 10.1097/00043764-198410000-00014.
Levine, RJ; Dalcorso, RD; Blunden, PB; Battigelli, MC. (1984c). The effects of occupational exposure on the respiratory health of West Virginia morticians. J Occup Med 26: 91–98.6707776
Levy, S; Nocentini, S; Billardon, C. (1983). Induction of cytogenetic effects in human fibroblast cultures after exposure to formaldehyde or X-rays. Mutat Res 119: 309–317. 10.1016/0165-7992(83)90179-3.6828066
Li, AM; Fung, CK; Yu, IT; Goggins, WB; Chan, GY; Chan, CK; Lau, AP; Leung, JO. (2019). Associations of wheeze during the first 18 months of life with indoor nitrogen dioxide, formaldehyde, and family history of asthma: a prospective cohort study. Hong Kong Med J 25 Suppl 3: 20–23.30792368
Li, F; Qin, Y; Gong, S; Zhang, H; Ding, S. (2020). Learning and memory impairment of mice caused by gaseous formaldehyde. Environ Res 184: 109318. 10.1016/j.envres.2020.109318.32151841
Li, G; Yang, J; Ling, S. (2015). Formaldehyde exposure alters miRNA expression profiles in the olfactory bulb. Inhal Toxicol 27: 1–7. 10.3109/08958378.2015.1062580.
Li, GY; Lee, HY; Choi, YJ; Lee, MO; Shin, HS; Kim, HY; Lee, SB; Lee, BH. (2008). Changes in the Expression of Ras-family Genes in Rats Exposed to Formaldehyde by Inhalation. Toxicological Research 24: 201–206. 10.5487/TR.2008.24.3.201.32038796
Li, L; Hua, L; He, Y; Bao, Y. (2017). Differential effects of formaldehyde exposure on airway inflammation and bronchial hyperresponsiveness in BALB/c and C57BL/6 mice. PLoS ONE 12: e0179231. 10.1371/journal.pone.0179231.28591193
Li, L; Xia, Y; Nguyen, A; Lai, YH; Feng, L; Mosmann, TR; Lo, D. (1999). Effects of Th2 cytokines on chemokine expression in the lung: IL-13 potently induces eotaxin expression by airway epithelial cells. J Immunol 162: 2477–2487.10072486
Li, R; Lu, ZS; Qiao, Y; Yao, HC; Yu, FF; Yang, X. (2004). Study on the formaldehyde-induced DNA damage with comet assay. Shi Yan Sheng Wu Xue Bao 37: 262–268.15511067
Li, W; Ray, RM; Gao, DL; Fitzgibbons, ED; Seixas, NS; Camp, JE; Wernli, KJ; Astrakianakis, G; Feng, Z; Thomas, DB; Checkoway, H. (2006). Occupational risk factors for nasopharyngeal cancer among female textile workers in Shanghai, China. Occup Environ Med 63: 39–44. 10.1136/oem.2005.021709.16361404
Li, Y; Song, Z; Ding, Y; Xin, Y, e; Wu, T; Su, T, ao; He, R; Tai, F; Lian, Z. (2016). Effects of formaldehyde exposure on anxiety-like and depression-like behavior, cognition, central levels of glucocorticoid receptor and tyrosine hydroxylase in mice. Chemosphere 144: 2004–2012. 10.1016/j.chemosphere.2015.10.102.26551198
Liao, S; Jiang, L; Zhang, X. (2010). [Effects of inhaled formaldehyde on learning and memory and expression of CaMK II in hippocampus of Wistar rats of different ages]. Chongqing Yike Daxue Xuebao 35: 342–344.
Liber, HL; Benforado, K; Crosby, RM; Simpson, D; Skopek, TR. (1989). Formaldehyde-induced and spontaneous alterations in human hprt DNA sequence and mRNA expression. Mutat Res 226: 31–37. 10.1016/0165-7992(89)90089-4.2716766
LICM (Lithium Ion Cell Manufacturers’ Coalition). (2006). Studies on formation and repair of formaldehyde-damaged DNA by detection of DNA-protein crosslinks and DNA breaks. Front Biosci 11: 991–997. 10.2741/1856.16146790
LICM (Lithium Ion Cell Manufacturers’ Coalition). (2008). Effect of inhaled formaldehyde on learning and memory of mice. Indoor Air 18: 77–83. 10.1111/j.1600-0668.2008.00524.x.18333987
Liebling, T; Rosenman, KD; Pastides, H; Griffith, RG; Lemeshow, S. (1984). Cancer mortality among workers exposed to formaldehyde. Am J Ind Med 5: 423–428. 10.1002/ajim.4700050602.6731443
Lilly, CM; Hall, AE; Rodger, IW; Kobzik, L; Haley, KJ; Drazen, JM. (1995). Substance P-induced histamine release in tracheally perfused guinea pig lungs. J Appl Physiol (1985) 78: 1234–1241. 10.1152/jappl.1995.78.4.1234.7542231
Lima, LF; Murta, GL; Bandeira, AC; Nardeli, CR; Lima, WG; Bezerra, FS. (2015). Short-term exposure to formaldehyde promotes oxidative damage and inflammation in the trachea and diaphragm muscle of adult rats. Ann Anat 202: 45–51. 10.1016/j.aanat.2015.08.003.26342159
Lin, D; Guo, Y; Yi, J; Kuang, D, an; Li, X; Deng, H; Huang, K, un; Guan, L, ei; He, Y; Zhang, X; Hu, D, ie; Zhang, Z; Zheng, H; Zhang, X; Mchale, CM; Zhang, L; Wu, T. (2013). Occupational exposure to formaldehyde and genetic damage in the peripheral blood lymphocytes of plywood workers. J Occup Health 55: 284–291. 10.1539/joh.12-0288-OA.23648472
Lin, Z; Luo, W; Li, H; Zhang, Y. (2005). The effect of endogenous formaldehyde on the rat aorta endothelial cells. Toxicol Lett 159: 134–143. 10.1016/j.toxlet.2005.05.003.15961263
Lindbohm, ML; Hemminki, K; Bonhomme, MG; Anttila, A; Rantala, K; Heikkila, P; Rosenberg, MJ. (1991). Effects of paternal occupational exposure on spontaneous abortions. Am J Public Health 81: 1029–1033. 10.2105/ajph.81.8.1029.1853994
Lindstrom, AB; Proffitt, D; Fortune, CR. (1995). Effects of modified residential construction on indoor air quality. Indoor Air 5: 258–269. 10.1111/j.1600-0668.1995.00005.x.
Lino-Dos-Santos-Franco, A; Amemiya, RM; de Oliveira, AP; Damazo, AS; Breithaupt-Faloppa, AC; Vitoretti, LB; Acceturi, BG; Tavares-De-Lima, W. (2013a). The putative role of ovary removal and progesterone when considering the effect of formaldehyde exposure on lung inflammation induced by ovalbumin. Clinics 68: 1528–1536. 10.6061/clinics/2013(12)09.24473511
Lino-Dos-Santos-Franco, A; Amemiya, RM; Ligeiro de Oliveira, AP; Breithaupt-Faloppa, AC; Damazo, AS; Oliveira-Filho, RM; Tavares-De-Lima, W. (2011a). Differential effects of female sex hormones on cellular recruitment and tracheal reactivity after formaldehyde exposure. Toxicol Lett 205: 327–335. 10.1016/j.toxlet.2011.06.023.21726612
Lino-Dos-Santos-Franco, A; Correa-Costa, M; Durão, AC; de Oliveira, AP; Breithaupt-Faloppa, AC; Bertoni, J; Oliveira-Filho, RM; Câmara, NO; Marcourakis, T; Tavares-De-Lima, W. (2011b). Formaldehyde induces lung inflammation by an oxidant and antioxidant enzymes mediated mechanism in the lung tissue. Toxicol Lett 207: 278–285. 10.1016/j.toxlet.2011.09.026.21983654
Lino-Dos-Santos-Franco, A; Domingos, HV; de Oliveira, AP; Breithaupt-Faloppa, AC; Peron, JP; Bolonheis, S; Muscará, MN; Oliveira-Filho, RM; Vargaftig, BB; Tavares-De-Lima, W. (2010). Differential effects of formaldehyde exposure on the cell influx and vascular permeability in a rat model of allergic lung inflammation. Toxicol Lett 197: 211–218.20658762
Lino-Dos-Santos-Franco, A; Gimenes-Júnior, JA; Ligeiro-De-Oliveira, AP; Breithaupt-Faloppa, AC; Acceturi, BG; Vitoretti, LB; Machado, ID; Oliveira-Filho, RM; Farsky, SHP; Moriya, HT; Tavares-De-Lima, W. (2013b). Formaldehyde inhalation reduces respiratory mechanics in a rat model with allergic lung inflammation by altering the nitric oxide/cyclooxygenase-derived products relationship. Food Chem Toxicol 59: 731–738. 10.1016/j.fct.2013.07.027.23871789
Lino dos Santos Franco, A; Damazo, AS; Beraldo de Souza, HR; Domingos, HV; Oliveira-Filho, RM; Oliani, SM; Costa, SK; Tavares de Lima, W. (2006). Pulmonary neutrophil recruitment and bronchial reactivity in formaldehyde-exposed rats are modulated by mast cells and differentially by neuropeptides and nitric oxide. Toxicol Appl Pharmacol 214: 35–42. 10.1016/j.taap.2005.11.014.16427670
Lino dos Santos Franco, A; Domingos, HV; Damazo, AS; Breithaupt-Faloppa, AC; de Oliveira, AP; Costa, SK; Oliani, SM; Oliveira-Filho, RM; Vargaftig, BB; Tavares-De-Lima, W. (2009). Reduced allergic lung inflammation in rats following formaldehyde exposure: Long-term effects on multiple effector systems. Toxicology 256: 157–163. 10.1016/j.tox.2008.11.011.19071189
Liteplo, RG; Meek, ME. (2003). Inhaled formaldehyde: Exposure estimation, hazard characterization, and exposure-response analysis [Review]. J Toxicol Environ Health B Crit Rev 6: 85–114. 10.1080/10937400306480.12587255
Liu, D; Zheng, Y; Li, B; Yao, H; Li, R; Zhang, Y; Yang, X. (2011). Adjuvant effects of gaseous formaldehyde on the hyper-responsiveness and inflammation in a mouse asthma model immunized by ovalbumin. J Immunotoxicol 8: 305–314. 10.3109/1547691X.2011.600738.21854218
Liu, KS; Huang, FY; Hayward, SB; Wesolowski, J; Sexton, K. (1991). Irritant effects of formaldehyde exposure in mobile homes. Environ Health Perspect 94: 91–94. 10.2307/3431298.1954947
Liu, L; Huang, Y; Feng, X; Chen, J; Duan, Y. (2019). Overexpressed Hsp70 alleviated formaldehyde-induced apoptosis partly via PI3K/Akt signaling pathway in human bronchial epithelial cells. Environ Toxicol 34: 495–504. 10.1002/tox.22703.30600586
Liu, QB; Wang, W; Jing, W. (2018a). Indoor air pollution aggravates asthma in Chinese children and induces the changes in serum level of miR-155. Int J Environ Health Res 29: 1–9. 10.1080/09603123.2018.1506569.30084259
Liu, QP; Zhou, DX; Lv, MQ; Ge, P; Li, YX; Wang, SJ. (2018b). Formaldehyde inhalation triggers autophagy in rat lung tissues. Toxicol Ind Health 748233718796347. 10.1177/0748233718796347.
Liu, W; Zhang, J; Hashim, JH; Jalaludin, J; Hashim, Z; Goldstein, BD. (2003). Mosquito coil emissions and health implications. Environ Health Perspect 111: 1454–1460. 10.1289/ehp.6286.12948883
Liu, Y, i; Ye, Z; Luo, H; Sun, M; Li, M, i; Fan, D; Chui, D. (2009a). Inhalative formaldehyde exposure enhances aggressive behavior and disturbs monoamines in frontal cortex synaptosome of male rats. Neurosci Lett 464: 113–116. 10.1016/j.neulet.2009.06.037.19545605
Liu, Y; Ye, Z; Yang, H; Zhou, L; Fan, D; He, S; Chui, D. (2010). Disturbances of soluble N-ethylmaleimide-sensitive factor attachment proteins in hippocampal synaptosomes contribute to cognitive impairment after repetitive formaldehyde inhalation in male rats. Neuroscience 169: 1248–1254. 10.1016/j.neuroscience.2010.05.061.20609425
Liu, Y; Yu, D; Xiao, S. (2017). Effects of chronic exposure to Formaldehyde on micronucleus rate of bone marrow cells in male mice. J Pak Med Assoc 67: 933–935.28585597
Liu, YR; Zhou, Y; Qiu, W; Zeng, JY; Shen, LL; Li, AP; Zhou, JW. (2009b). Exposure to formaldehyde induces heritable DNA mutations in mice. J Toxicol Environ Health A 72: 767–773. 10.1080/15287390902841615.19492241
Löfstedt, H; Westberg, H; Seldén, AI; Bryngelsson, IL; Svartengren, M. (2011a). Respiratory symptoms and lung function in foundry workers using the hot box method: A 4-year follow-up. J Occup Environ Med 53: 1425–1429. 10.1097/JOM.0b013e3182363c17.22173285
Löfstedt, H; Westberg, H; Seldén, AI; Lundholm, C; Svartengren, M. (2009). Respiratory symptoms and lung function in foundry workers exposed to low molecular weight isocyanates. Am J Ind Med 52: 455–463. 10.1002/ajim.20693.19288497
Löfstedt, H; Westberg, H; Seldén, AI; Rudblad, S; Bryngelsson, IL; Ngo, Y; Svartengren, M. (2011b). Nasal and ocular effects in foundry workers using the hot box method. J Occup Environ Med 53: 43–48. 10.1097/JOM.0b013e318181ff05cc.21187796
Logue, J; Barrick, M; Jessup, G. (1986). Mortality of radiologists and pathologists in the radiation registry of physicians. J Occup Med 28: 91–99.3950788
Lorenti Garcia, C; Mechilli, M; Proietti De Santis, L; Schinoppi, A; Kobos, K; Palitti, F. (2009). Relationship between DNA lesions, DNA repair and chromosomal damage induced by acetaldehyde. Mutat Res 662: 3–9. 10.1016/j.mrfmmm.2008.11.008.19084543
Lourenço, O; Fonseca, AM; Taborda-Barata, L. (2016). Human CD8+ T Cells in Asthma: Possible Pathways and Roles for NK-Like Subtypes [Review]. 7: 638. 10.3389/fimmu.2016.00638.
Lovreglio, P; Carrus, A; Iavicoli, S; Drago, I; Persechino, B; Soleo, L. (2009). Indoor formaldehyde and acetaldehyde levels in the province of Bari, South Italy, and estimated health risk. J Environ Monit 11: 955–961. 10.1039/b819843h.19436853
Lu, K. (2009) Molecular binding of formaldehyde to dna and proteins. (Doctoral Dissertation). University of North Carolina at Chapel Hill, Chapel Hill, NC.
Lu, K; Boysen, G; Gao, L; Collins, LB; Swenberg, JA. (2008). Formaldehyde-induced histone modifications in vitro. Chem Res Toxicol 21: 1586–1593. 10.1021/tx8000576.18656964
Lu, K; Collins, LB; Ru, H; Bermudez, E; Swenberg, JA. (2010a). Distribution of DNA adducts caused by inhaled formaldehyde is consistent with induction of nasal carcinoma but not leukemia. Toxicol Sci 116: 441–451. 10.1093/toxsci/kfq061.20176625
Lu, K; Craft, S; Nakamura, J; Moeller, BC; Swenberg, JA. (2012a). Use of LC-MS/MS and stable isotopes to differentiate hydroxymethyl and methyl DNA adducts from formaldehyde and nitrosodimethylamine. Chem Res Toxicol 25: 664–675. 10.1021/tx200426b.22148432
Lu, K; Gul, H; Upton, PB; Moeller, BC; Swenberg, JA. (2012b). Formation of hydroxymethyl DNA adducts in rats orally exposed to stable isotope labeled methanol. Toxicol Sci 126: 28–38. 10.1093/toxsci/kfr328.22157354
Lu, K; Moeller, B; Doyle-Eisele, M; Mcdonald, J; Swenberg, JA. (2011). Molecular dosimetry of N2-hydroxymethyl-dG DNA adducts in rats exposed to formaldehyde. Chem Res Toxicol 24: 159–161. 10.1021/tx1003886.21155545
Lu, Y; Wang, D; Ma, C; Yang, H. (2010b). The effect of activated carbon adsorption on the photocatalytic removal of formaldehyde. Build Environ 45: 615–621. 10.1016/j.buildenv.2009.07.019.
Lu, Z; Li, CM; Qiao, Y; Liu, Y; Yan, Y; Yang, X. (2005). Type II vanilloid receptor signaling system: One of the possible mechanisms for the rise in asthma cases. Front Biosci 10: 2527–2533. 10.2741/1717.15970515
Luce, D; Gérin, M; Leclerc, A; Morcet, JF; Brugère, J; Goldberg, M. (1993). Sinonasal cancer and occupational exposure to formaldehyde and other substances. Int J Cancer 53: 224–231. 10.1002/ijc.2910530209.8425759
Luce, D; Leclerc, A; Bégin, D; Demers, PA; Gérin, M; Orlowski, E; Kogevinas, M; Belli, S; Bugel, I; Bolm-Audorff, U; Brinton, LA; Comba, P; Hardell, L; Hayes, RB; Magnani, C; Merler, E; Preston-Martin, S; Vaughan, TL; Zheng, W; Boffetta, P. (2002). Sinonasal cancer and occupational exposures: a pooled analysis of 12 case–control studies. Cancer Causes Control 13: 147–157. 10.1023/A:1014350004255.11936821
Luce, D; Leclerc, A; Morcet, JF; Casal-Lareo, A; Gérin, M; Brugère, J; Haguenoer, JM; Goldberg, M. (1992). Occupational risk factors for sinonasal cancer: A case-control study in France. Am J Ind Med 21: 163–175. 10.1002/ajim.4700210206.1536152
Luebeck, EG; Buchmann, A; Stinchcombe, S; Moolgavkar, SH; Schwarz, M. (2000). Effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin on initiation and promotion of GST-P-positive foci in rat liver: A quantitative analysis of experimental data using a stochastic model. Toxicol Appl Pharmacol 167: 63–73. 10.1006/taap.2000.8980.10936080
Luebeck, EG; Grasl-Kraupp, B; Timmermann-Trosiener, I; Bursch, W; Schulte-Hermann, R; Moolgavkar, SH. (1995). Growth kinetics of enzyme-altered liver foci in rats treated with phenobarbital or alpha-hexachlorocyclohexane. Toxicol Appl Pharmacol 130: 304–315. 10.1006/taap.1995.1035.7532877
Lundberg, JM; Saria, A. (1983). Capsaicin-induced desensitization of airway mucosa to cigarette smoke, mechanical and chemical irritants [Letter]. Nature 302: 251–253. 10.1038/302251a0.6188055
Luo, YL; Guo, HM; Zhang, YL; Chen, PX; Zhu, YX; Huang, JH; Zhou, WL. (2013). Cellular mechanism underlying formaldehyde-stimulated Cl- secretion in rat airway epithelium. PLoS ONE 8: e54494. 10.1371/journal.pone.0054494.23372735
Lyapina, M; Zhelezova, G; Petrova, E; Boev, M. (2004). Flow cytometric determination of neutrophil respiratory burst activity in workers exposed to formaldehyde. Int Arch Occup Environ Health 77: 335–340. 10.1007/s00420-004-0516-3.15127208
Ma, H; Song, X; Zhang, W; Ling, X; Yang, X; Wu, W; Lou, K; Xu, H. (2020). Formaldehyde inhibits development of T lymphocytes in mice. Toxicol Environ Chem 102: 473–489. 10.1080/02772248.2020.1815202.
Ma, TH; Harris, MM. (1988). Review of the genotoxicity of formaldehyde [Review]. Mutat Res Rev Genet Toxicol 196: 37–59. 10.1016/0165-1110(88)90027-9.
Macedo, R; Gomes, F; Leal, M; Barioni, E; Braga, T; Camara, N; Farsky, S; Franco, ALD. (2016a). Low level laser treatment reduces oxidative stress induced by formaldehyde exposure by the modulation of gene expression of oxidant and antioxidant enzymes in the lung tissue [Abstract]. Lasers Surg Med 48: 58. 10.1002/lsm.22485.
Macedo, RS; Leal, MP; Braga, TT; Barioni, ED; Duro, S; Ratto Tempestini Horliana, AC; Saraiva Camara, NO; Marcourakis, T; Poliselli Farsky, SH; Lino-Dos-Santos-Franco, A. (2016b). Photobiomodulation Therapy Decreases Oxidative Stress in the Lung Tissue after Formaldehyde Exposure: Role of Oxidant/Antioxidant Enzymes. Mediators Inflamm 2016: 9303126. 10.1155/2016/9303126.27293324
Mackenzie, RA; Burke, D; Skuse, NF; Lethlean, AK. (1975). Fibre function and perception during cutaneous nerve block. J Neurol Neurosurg Psychiatry 38: 865–873. 10.1136/jnnp.38.9.865.1185225
Mackerer, CR; Angelosanto, FA; Blackburn, GR; Schreiner, CA. (1996). Identification of formaldehyde as the metabolite responsible for the mutagenicity of methyl tertiary-butyl ether in the activated mouse lymphoma assay. Proc Soc Exp Biol Med 212: 338–341. 10.3181/00379727-212-44023.8751991
Macpherson, LJ; Xiao, B; Kwan, KY; Petrus, MJ; Dubin, AE; Hwang, S; Cravatt, B; Corey, DP; Patapoutian, A. (2007). An ion channel essential for sensing chemical damage. J Neurosci 27: 11412–11415. 10.1523/JNEUROSCI.3600-07.2007.17942735
Maddalena, RL; Russell, M; Sullivan, DP; Apte, MG. (2008). Interim report: VOC and aldehyde emissions in four FEMA temporary housing units. Maddalena, RL; Russell, M; Sullivan, DP; Apte, MG.
Madison, RE; Broughton, A; Thrasher, JD. (1991). Immunologic biomarkers associated with an acute exposure to exothermic byproducts of a ureaformaldehyde spill. Environ Health Perspect 94: 219–223. 10.2307/3431314.1683282
Madureira, J; Paciência, I; Cavaleiro-Rufo, J; de Oliveira Fernandes, E. (2016). Indoor pollutant exposure among children with and without asthma in Porto, Portugal, during the cold season. Environ Sci Pollut Res Int 23: 20539–20552. 10.1007/s11356-016-7269-x.27464657
Madureira, J; Paciência, I; Ramos, E; Barros, H; Pereira, C; Teixeira, JP; Fernandes, E. (2015). Children’s Health and Indoor Air Quality in Primary Schools and Homes in Portugal-Study Design. J Toxicol Environ Health A 78: 915–930. 10.1080/15287394.2015.1048926.26167757
Maes, T; Joos, GF; Brusselle, GG. (2012). Targeting interleukin-4 in asthma: lost in translation? [Review]. Am J Respir Cell Mol Biol 47: 261–270. 10.1165/rcmb.2012-0080TR.22538865
Maffei, F; Angelini, S; Forti, GC; Lodi, V; Violante, FS; Mattioli, S; Hrelia, P. (2002). Micronuclei frequencies in hospital workers occupationally exposed to low levels of ionizing radiation: influence of smoking status and other factors. Mutagenesis 17: 405–409. 10.1093/mutage/17.5.405.12202628
Magaña-Schwencke, N; Ekert, B. (1978). Biochemical analysis of damage induced in yeast by formaldehyde. II. Induction of cross-links between DNA and protein. Mutat Res 51: 11–19. 10.1016/0027-5107(78)90003-9.353537
Magaña-Schwencke, N; Ekert, B; Moustacchi, E. (1978). Biochemical analysis of damage induced in yeast by formaldehyde. I. Induction of single-strand breaks in DNA and their repair. Mutat Res 50: 181–193. 10.1016/0027-5107(78)90023-4.349372
Magaña-Schwencke, N; Moustacchi, E. (1980). Biochemical analysis of damage induced in yeast by formaldehyde III. Repair of induced cross-links between DNA and proteins in the wild-type and in excision-deficient strains. Mutat Res 70: 29–35. 10.1016/0027-5107(80)90055-X.6988706
Magnani, C; Comba, P; Ferraris, F; Ivaldi, C; Meneghin, M; Terracini, B. (1993). A case-control study of carcinomas of the nose and paranasal sinuses in the woolen textile manufacturing industry. Arch Environ Health 48: 94–97. 10.1080/00039896.1993.9938401.8476310
Maiellaro, M; Correa-Costa, M; Vitoretti, LB; Gimenes Junior, JA; Saraiva Camara, NO; Tavares-De-Lima, W; Poliselli Farsky, SH; Lino-Dos-Santos-Franco, A. (2014). Exposure to low doses of formaldehyde during pregnancy suppresses the development of allergic lung inflammation in offspring. Toxicol Appl Pharmacol 278: 266–274. 10.1016/j.taap.2014.05.003.24844129
Maiellaro, M; Macedo, RS; Mendes, E; Tavares-De-Lima, W; Ferreira, CM; Lino-Dos-Santos-Franco, A. (2016). High dose of formaldehyde exposure during pregnancy increases neutrophils lung influx evoked by ovalbumin in the offspring. Inflamm Res 65: 179–181. 10.1007/s00011-015-0901-2.26608501
Main, DM; Hogan, TJ. (1983). Health effects of low level exposure to formaldehyde. J Occup Environ Med 25: 896–900. 10.1097/00043764-198312000-00013.
Malaka, T; Kodama, AM. (1990). Respiratory health of plywood workers occupationally exposed to formaldehyde. Arch Environ Health 45: 288–294. 10.1080/00039896.1990.10118748.2256713
Malek, FA; Möritz, KU; Fanghänel, J. (2003a). Formaldehyde inhalation & open field behaviour in rats. Indian J Med Res 118: 90–96.14680205
Malek, FA; Möritz, KU; Fanghänel, J. (2003b). A study on specific behavioral effects of formaldehyde in the rat. J Exp Anim Sci 42: 160–170. 10.1016/S0939-8600(03)80009-3.
Malek, FA; Möritz, KU; Fanghänel, J. (2003c). A study on the effect of inhalative formaldehyde exposure on water labyrinth test performance in rats. Ann Anat 185: 277–285. 10.1016/S0940-9602(03)80040-7.12801093
Malek, FA; Möritz, KU; Fanghänel, J. (2004). Effects of a single inhalative exposure to formaldehyde on the open field behavior of mice. Int J Hyg Environ Health 207: 151–158. 10.1078/1438-4639-00268.15031957
Malker, HSR; Mclaughlin, JK; Weiner, JA; Silverman, DT; Blot, WJ; JLE, E; Fraumeni, J, r, J. F. (1990). Occupational risk factors for nasopharyngeal cancer in Sweden. Br J Ind Med 47: 213–214. 10.1136/oem.47.3.213.2328228
Mallet, ML. (2002). Pathophysiology of accidental hypothermia [Review]. QJM 95: 775–785. 10.1093/qjmed/95.12.775.12454320
Mallia, P; Message, SD; Contoli, M; Gray, K; Telcian, A; Laza-Stanca, V; Papi, A; Stanciu, LA; Elkin, S; Kon, OM; Johnson, M; Johnston, SL. (2014). Lymphocyte subsets in experimental rhinovirus infection in chronic obstructive pulmonary disease. Respir Med 108: 78–85. 10.1016/j.rmed.2013.09.010.24099891
Marcon, A; Fracasso, ME; Marchetti, P; Doria, D; Girardi, P; Guarda, L; Pesce, G; Pironi, V; Ricci, P; de Marco, R. (2014). Outdoor formaldehyde and NO2 exposures and markers of genotoxicity in children living near chipboard industries. Environ Health Perspect 122: 639–645. 10.1289/ehp.1307259.24694350
Marinari, UM; Ferro, M; Sciaba, L; Finollo, R; Bassi, AM; Brambilla, G. (1984). DNA-damaging activity of biotic and xenobiotic aldehydes in Chinese hamster ovary cells. Cell Biochem Funct 2: 243–248. 10.1002/cbf.290020411.6518624
Marks, GB; Ezz, W; Aust, N; Toelle, BG; Xuan, W; Belousova, E; Cosgrove, C; Jalaludin, B; Smith, WT. (2010). Respiratory health effects of exposure to low-NOx unflued gas heaters in the classroom: A double-blind, cluster-randomized, crossover study. Environ Health Perspect 118: 1476–1482. 10.1289/ehp.1002186.20663737
Marnett, LJ; Hurd, HK; Hollstein, MC; Levin, DE; Esterbauer, H; Ames, BN. (1985). Naturally occurring carbonyl compounds are mutagens in Salmonella tester strain TA104. Mutat Res Fundam Mol Mech Mutagen 148: 25–34. 10.1016/0027-5107(85)90204-0.
Maronpot, RR; Miller, RA; Clarke, WJ; Westerberg, RB; Decker, JR; Moss, OR. (1986). Toxicity of formaldehyde vapor in B6C3F1 mice exposed for 13 weeks. Toxicology 41: 253–266. 10.1016/0300-483X(86)90180-0.3775776
Marsh, G; Youk, A; Stone, R; Buchanich, J; Gula, M; Smith, T; Quinn, M. (2001). Historical cohort study of US man-made vitreous fiber production workers: I. 1992 fiberglass cohort follow-up: Initial findings. J Occup Environ Med 43: 741–756. 10.1097/00043764-200109000-00004.11561358
Marsh, GM; Morfeld, P; Zimmerman, SD; Liu, Y; Balmert, LC. (2016). An updated re-analysis of the mortality risk from nasopharyngeal cancer in the National Cancer Institute formaldehyde worker cohort study. J Occup Med Toxicol 11: 8. 10.1186/s12995-016-0097-6.26937249
Marsh, GM; Youk, AO; Buchanich, JM; Cassidy, LD; Lucas, LJ; Esmen, NA; Gathuru, IM. (2002). Pharyngeal cancer mortality among chemical plant workers exposed to formaldehyde. Toxicol Ind Health 18: 257–268. 10.1191/0748233702th149oa.14992463
Marsh, GM; Youk, AO; Buchanich, JM; Erdal, S; Esmen, NA. (2007). Work in the metal industry and nasopharyngeal cancer mortality among formaldehyde-exposed workers. Regul Toxicol Pharmacol 48: 308–319. 10.1016/j.yrtph.2007.04.006.17544557
Martin, CN; McDermid, AC; Garner, RC. (1978). Testing of known carcinogens and noncarcinogens for their ability to induce unscheduled DNA synthesis in HeLa cells. Cancer Res 38: 2621–2627.667855
Martin, WJ. (1990). A teratology study of inhaled formaldehyde in the rat. Reprod Toxicol 4: 237–239. 10.1016/0890-6238(90)90065-4.2136043
Matanoski, GM. (1989). Risks of pathologists exposed to formaldehyde (final report). (DHHS Grant No. 5 R01-OH-01511-03). Baltimore, MD: Johns Hopkins University Department of Epidemiology. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB91173682.
Matsunaga, I; Miyake, Y; Yoshida, T; Miyamoto, S; Ohya, Y; Sasaki, S; Tanaka, K; Oda, H; Ishiko, O; Hirota, Y; Group, OMaCHS. (2008). Ambient formaldehyde levels and allergic disorders among Japanese pregnant women: Baseline data from the Osaka maternal and child health study. Ann Epidemiol 18: 78–84. 10.1016/j.annepidem.2007.07.095.18063241
Matsuoka, T; Takaki, A; Ohtaki, H; Shioda, S. (2010). Early changes to oxidative stress levels following exposure to formaldehyde in ICR mice. J Toxicol Sci 35: 721–730. 10.2131/jts.35.721.20930466
Mauderly, JL. (1986). Respiration of F344 rats in nose-only inhalation exposure tubes. J Appl Toxicol 6: 25–30. 10.1002/jat.2550060106.3958425
Mayer, AK; Dalpke, AH. (2007). Regulation of local immunity by airway epithelial cells [Review]. Arch Immunol Ther Exp 55: 353–362. 10.1007/s00005-007-0041-7.
Mayr, SI; Hafizovic, K; Waldfahrer, F; Iro, H; Kütting, B. (2010). Characterization of initial clinical symptoms and risk factors for sinonasal adenocarcinomas: results of a case-control study. Int Arch Occup Environ Health 83: 631–638. 10.1007/s00420-009-0479-5.19885670
Mazzone, SB; Undem, BJ. (2016). Vagal afferent innervation of the airways in health and disease [Review]. Physiol Rev 96: 975–1024. 10.1152/physrev.00039.2015.27279650
Mcghee, JD; von Hippel, PH. (1975a). Formaldehyde as a probe of DNA structure. I. Reaction with exocyclic amino groups of DNA bases. Biochemistry 14: 1281–1296. 10.1021/bi00677a029.235285
Mcghee, JD; von Hippel, PH. (1975b). Formaldehyde as a probe of DNA structure. II. Reaction with endocyclic imino groups of DNA bases. Biochemistry 14: 1297–1303. 10.1021/bi00677a030.235286
Mcnamara, CR; Mandel-Brehm, J; Bautista, DM; Siemens, J, an; Deranian, KL; Zhao, M; Hayward, NJ; Chong, JA; Julius, D; Moran, MM; Fanger, CM. (2007). TRPA1 mediates formalin-induced pain. Proc Natl Acad Sci USA 104: 13525–13530. 10.1073/pnas.0705924104.17686976
Medoff, BD; Thomas, SY; Banerji, A; Wain, JC; Zhang, H; Lilly, CM; Ginns, LC; Luster, AD. (2005). Pathogenic T-cell recruitment into the airway in human disease. Ann N Y Acad Sci 220–241. 10.1196/annals.1358.026.
Mei, YF; Duan, CL; Li, XX; Zhao, Y; Cao, FH; Shang, S; Ding, SM; Yue, XP; Gao, G; Yang, H; Shen, LX; Feng, XY; Jia, JP; Tong, ZQ; Yang, X. (2016). Reduction of Endogenous Melatonin Accelerates Cognitive Decline in Mice in a Simulated Occupational Formaldehyde Exposure Environment. Int J Environ Res Public Health 13. 10.3390/ijerph13030258.
Meister, A; Anderson, ME. (1983). Glutathione [Review]. Annu Rev Biochem 52: 711–760. 10.1146/annurev.bi.52.070183.003431.6137189
Meng, F; Bermudez, E; Mckinzie, PB; Andersen, ME; III, CH; Parsons, BL. (2010). Measurement of tumor-associated mutations in the nasal mucosa of rats exposed to varying doses of formaldehyde. Regul Toxicol Pharmacol 57: 274–283. 10.1016/j.yrtph.2010.03.007.20347909
Merk, O; Speit, G. (1998). Significance of formaldehyde-induced DNA-protein crosslinks for mutagenesis. Environ Mol Mutagen 32: 260–268. 10.1002/(SICI)1098-2280(1998)32:3<260::AID-EM9>3.0.CO;2-M.9814441
Merk, O; Speit, G. (1999). Detection of crosslinks with the comet assay in relationship to genotoxicity and cytotoxicity. Environ Mol Mutagen 33: 167–172. 10.1002/(sici)1098-2280(1999)33:2<167::aid-em9>3.0.co;2-d.10217071
Merler, E; Baldasseroni, A; laria, R; Faravelli, P; Agostini, R; Pisa, R; Berrino, F. (1986). On the causal association between exposure to leather dust and nasal cancer: Further evidence from a case-control study. Br J Ind Med 43: 91–95. 10.1136/oem.43.2.91.3947574
Message, SD; Laza-Stanca, V; Mallia, P; Parker, HL; Zhu, J, ie; Kebadze, T; Contoli, M; Sanderson, G; Kon, O, nnM; Papi, A; Jeffery, PK; Stanciu, LA; Johnston, SL. (2008). Rhinovirus-induced lower respiratory illness is increased in asthma and related to virus load and Th1/2 cytokine and IL-10 production. Proc Natl Acad Sci USA 105: 13562–13567. 10.1073/pnas.0804181105.18768794
Meyers, AR; Pinkerton, LE; Hein, MJ. (2013). Cohort mortality study of garment industry workers exposed to formaldehyde: Update and internal comparisons. Am J Ind Med 56: 1027–1039. 10.1002/ajim.22199.23788124
Mi, L; Sui, J; Wu, Y; Liang, G; Zhang, Y; Pu, Y; Tian, Y; Liu, S; Jiang, L. (2019). Bioinspired in vitro lung airway model for inflammatory analysis via hydrophobic nanochannel membrane with joint three-phase interface. Anal Chem 91: 15804–15810. 10.1021/acs.analchem.9b04114.31718146
Mi, YH; Norbäck, D; Tao, J; Mi, YL; Ferm, M. (2006). Current asthma and respiratory symptoms among pupils in Shanghai, China: Influence of building ventilation, nitrogen dioxide, ozone, and formaldehyde in classrooms. Indoor Air 16: 454–464. 10.1111/j.1600-0668.2006.00439.x.17100666
Migliore, L; Ventura, L; Barale, R; Loprieno, N; Castellino, S; Pulci, R. (1989). Micronuclei and nuclear anomalies induced in the gastro-intestinal epithelium of rats treated with formaldehyde. Mutagenesis 4: 327–334. 10.1093/mutage/4.5.327.2687625
Miller, FJ; Conolly, RB; Kimbell, JS. (2017). An updated analysis of respiratory tract cells at risk for formaldehyde carcinogenesis. Inhal Toxicol 29: 586–597. 10.1080/08958378.2018.1430191.29405084
Milton, DK; Wypij, D; Kriebel, D; Walters, MD; Hammond, SK; Evans, JS. (1996). Endotoxin exposure-response in a fiberglass manufacturing facility. Am J Ind Med 29: 3–13. 10.1002/(SICI)1097-0274(199601)29:1<3::AID-AJIM2>3.0.CO;2-V.8808037
Mittrücker, HW; Visekruna, A; Huber, M. (2014). Heterogeneity in the differentiation and function of CD8⁺ T cells [Review]. Arch Immunol Ther Exp 62: 449–458. 10.1007/s00005-014-0293-y.
Miyachi, T; Tsutsui, T. (2005). Ability of 13 chemical agents used in dental practice to induce sister-chromatid exchanges in Syrian hamster embryo cells. Odontology 93: 24–29. 10.1007/s10266-005-0055-8.16170472
Moeller, BC; Lu, K; Doyle-Eisele, M; Mcdonald, J; Gigliotti, A; Swenberg, JA. (2011). Determination of N2-hydroxymethyl-dG adducts in the nasal epithelium and bone marrow of nonhuman primates following 13CD2-formaldehyde inhalation exposure. Chem Res Toxicol 24: 162–164. 10.1021/tx1004166.21222454
Mohammad `pour, AA; Maleki, M. (2011). Effect of formaldehyde exposure on pulmonary function tests of veterinary students in anatomy laboratory. Journal of Applied Animal Research 39: 114–116. 10.1080/09712119.2011.558678.
Möhner, M; Liu, Y; Marsh, GM. (2019). New insights into the mortality risk from nasopharyngeal cancer in the national cancer institute formaldehyde worker cohort study. J Occup Med Toxicol 14: 4. 10.1186/s12995-019-0224-2.30828355
Monfared, AL. (2012). Histomorphological and ultrastructural changes of the placenta in mice exposed to formaldehyde. Toxicol Ind Health 30: 174–181. 10.1177/0748233712452603.22778113
Monteiro-Riviere, NA; Popp, JA. (1986). Ultrastructural evaluation of acute nasal toxicity in the rat respiratory epithelium in response to formaldehyde gas. Fundam Appl Toxicol 6: 251–262. 10.1016/0272-0590(86)90238-1.3699315
Monticello, TM; Gross, EA; Morgan, KT. (1993). Cell Proliferation and Nasal Carcinogenesis. Environ Health Perspect 101: 121. 10.2307/3431854.
Monticello, TM; Miller, FJ; Morgan, KT. (1991). Regional increases in rat nasal epithelial cell proliferation following acute and subchronic inhalation of formaldehyde. Toxicol Appl Pharmacol 111: 409–421. 10.1016/0041-008X(91)90246-B.1746023
Monticello, TM; Morgan, KT. (1994). Cell proliferation and formaldehyde-induced respiratory carcinogenesis [Review]. Risk Anal 14: 313–319. 10.1111/j.1539-6924.1994.tb00246.x.8029503
Monticello, TM; Morgan, KT. (1997). Chemically-induced nasal carcinogenesis and epithelial cell proliferation: A brief review [Review]. Mutat Res Fundam Mol Mech Mutagen 380: 33–41. 10.1016/S0027-5107(97)00125-5.
Monticello, TM; Morgan, KT; Everitt, JI; Popp, JA. (1989). Effects of formaldehyde gas on the respiratory tract of rhesus monkeys: Pathology and cell proliferation. Am J Pathol 134: 515–527.2923182
Monticello, TM; Morgan, KT; Hurtt, ME. (1990). Unit length as the denominator for quantitation of cell proliferation in nasal epithelia. Toxicol Pathol 18: 24–31. 10.1177/019262339001800104.2194274
Monticello, TM; Swenberg, JA; Gross, EA; Leininger, JR; Kimbell, JS; Seilkop, S; Starr, TB; Gibson, JE; Morgan, KT. (1996). Correlation of regional and nonlinear formaldehyde-induced nasal cancer with proliferating populations of cells. Cancer Res 56: 1012–1022.8640755
Moolgavkar, SH. (1994). Biological models of carcinogenesis and quantitative cancer risk assessment. Risk Anal 14: 879–882. 10.1111/j.1539-6924.1994.tb00049.x.7846320
Moolgavkar, SH; Dewanji, A; Venzon, DJ. (1988). A stochastic two-stage model for cancer risk assessment. I. The hazard function and the probability of tumor. Risk Anal 8: 383–392. 10.1111/j.1539-6924.1988.tb00502.x.3201016
Moolgavkar, SH; Knudson, AJ. (1981). Mutation and cancer: A model for human carcinogenesis. J Natl Cancer Inst 66: 1037–1052.6941039
Moolgavkar, SH; Luebeck, EG. (1992). Interpretation of labeling indices in the presence of cell death. Carcinogenesis 13: 1007–1010. 10.1093/carcin/13.6.1007.1600603
Moolgavkar, SH; Luebeck, EG; Krewski, D; Zielinski, JM. (1993). Radon, cigarette smoke, and lung cancer: A re-analysis of the Colorado Plateau uranium miners’ data. Epidemiology 4: 204–217.8512985
Moolgavkar, SH; Venzon, DJ. (1979). Two-event models for carcinogenesis: Incidence curves for childhood and adult tumors. Math Biosci 47: 55–77. 10.1016/0025-5564(79)90005-1.
Moorman, JE; Akinbami, LJ; Bailey, CM; Zahran, HS; King, ME; Johnson, CA; Liu, X. (2012). National surveillance of asthma: United States, 2001-2010. In Vital & Health Statistics Series 3: Analytical and Epidemiological Studies, no 35. Hyattsville, MD: U.S. Department of Health and Human Services, Public Health Service, National Center for Health Statistics. https://www.cdc.gov/nchs/data/series/sr_03/sr03_035.pdf.
Morgan, DL; Dixon, D; King, DH; Travlos, GS; Herbert, RA; French, JE; Tokar, EJ; Waalkes, MP; Jokinen, MP. (2017). NTP research report on absence of formaldehyde-induced neoplasia in Trp53 haploinsufficient mice exposed by inhalation. (Research Report 3). Research Triangle Park, NC: National Toxicology Program. 10.22427/NTP-RR-3.
Morgan, KT. (1983). Localization of areas of inhibition of nasal mucociliary function in rats following in vivo exposure to formaldehyde. Am Rev Respir Dis 127: 166.6830032
Morgan, KT. (1997). A brief review of formaldehyde carcinogenesis in relation to rat nasal pathology and human health risk assessment [Review]. Toxicol Pathol 25: 291–305. 10.1177/019262339702500307.9210261
Morgan, KT; Gross, EA; Patterson, DL. (1986a). Distribution, progression, and recovery of acute formaldehyde-induced inhibition of nasal mucociliary function in F-344 rats. Toxicol Appl Pharmacol 86: 448–456. 10.1016/0041-008X(86)90372-8.3787637
Morgan, KT; Jiang, XZ; Starr, TB; Kerns, WD. (1986b). More precise localization of nasal tumors associated with chronic exposure of F-344 rats to formaldehyde gas. Toxicol Appl Pharmacol 82: 264–271. 10.1016/0041-008X(86)90201-2.3945953
Morgan, KT; Kimbell, JS; Monticello, TM; Patra, AL; Fleishman, A. (1991). Studies of inspiratory airflow patterns in the nasal passages of the F344 rat and rhesus monkey using nasal molds: Relevance to formaldehyde toxicity. Toxicol Appl Pharmacol 110: 223–240. 10.1016/S0041-008X(05)80005-5.1891770
Morgan, KT; Patterson, DL; Gross, EA. (1984). Frog palate mucociliary apparatus: Structure, function, and response to formaldehyde gas. Fundam Appl Toxicol 4: 58–68. 10.1016/0272-0590(84)90219-7.6607184
Morgan, KT; Patterson, DL; Gross, EA. (1986c). Responses of the nasal mucociliary apparatus of F-344 rats to formaldehyde gas. Toxicol Appl Pharmacol 82: 1–13. 10.1016/0041-008X(86)90431-X.3945936
Morgan, KT; Patterson, DL; Gross, EA. (1983). Formaldehyde and the nasal mucociliary apparatus. In JJ Clary; JE Gibson; RS Waritz (Eds.), Formaldehyde: toxicology, epidemiology, mechanisms (pp. 193–209). New York, NY: Marcel Dekker, Inc.
Mori, M; Matsumoto, Y; Kushino, N; Morimatsu, Y; Hoshiko, M; Saga, T; Yamaki, K; Ishitake, T. (2016). Comparison of subjective symptoms associated with exposure to low levels of formaldehyde between students enrolled and not enrolled in a gross anatomy course. Environ Health Prev Med 21: 34–41. 10.1007/s12199-015-0497-8.26498185
Morita, T; Asano, N; Awogi, T; Sasaki, YF; Sato, S; Shimada, H; Sutou, S; Suzuki, T; Wakata, A; Sofuni, T; Hayashi, M. (1997). Evaluation of the rodent micronucleus assay in the screening of IARC carcinogens (groups 1, 2A and 2B) the summary report of the 6th collaborative study by CSGMT/JEMS MMS [Review]. Mutat Res 389: 3–122. 10.1016/S1383-5718(96)00070-8.9062586
Moser, B; Bodrogi, F; Eibl, G; Lechner, M; Rieder, J; Lirk, P. (2005). Mass spectrometric profile of exhaled breath - field study by PTR-MS. Respir Physiol Neurobiol 145: 295–300. 10.1016/j.resp.2004.02.002.15705543
Mostafa, GA. (2009). Neurogenic inflammation and allergy [Review]. Egypt J Pediatr Allergy Immunol 7: 45–58.
Mueller, JU; Bruckner, T; Triebig, G. (2013). Exposure study to examine chemosensory effects of formaldehyde on hyposensitive and hypersensitive males. Int Arch Occup Environ Health 86: 107–117. 10.1007/s00420-012-0745-9.22371090
Müller, B; Schulz, G; Mehlin, A; Herzen, J; Lang, S; Holme, M; Zanette, I; Hieber, S; Deyhle, H; Beckmann, F; Pfeiffer, F; Weitkamp, T. (2012). Grating-based tomography of human tissues. In A Momose; W Yashiro (Eds.), Proceedings of the International Workshop on X-Ray and Neutron Phase Imaging with Gratings (pp. 107–112). Melville, NY: American Institute of Physics. 10.1063/1.4742277.
Müller, W; Engelhart, G; Herbold, B; Jäckh, R; Jung, R. (1993). Evaluation of mutagenicity testing with Salmonella typhimurium TA102 in three different laboratories. Environ Health Perspect 101: 33–36. 10.1289/ehp.101-1521147.
Mundt, KA; Gallagher, AE; Dell, LD; Natelson, EA; Boffetta, P; Gentry, PR. (2017). Does occupational exposure to formaldehyde cause hematotoxicity and leukemia-specific chromosome changes in cultured myeloid progenitor cells? [Review]. Crit Rev Toxicol 47: 1–11. 10.1080/10408444.2017.1301878.27537422
Murta, GL; Duarte Campos, KK; Balthar Bandeira, A; Diniz, MF; Costa, G; Costa, DC; Talvani, A; Lima, WG; Bezerra, FS. (2016). Oxidative effects on lung inflammatory response in rats exposed to different concentrations of formaldehyde. Environ Pollut 211: 206–213. 10.1016/j.envpol.2015.12.054.26774767
Musak, L; Smerhovsky, Z; Halasova, E; Osina, O; Letkova, L; Vodickova, L; Polakova, V; Buchancova, J; Hemminki, K; Vodicka, P. (2013). Chromosomal damage among medical staff occupationally exposed to volatile anesthetics, antineoplastic drugs, and formaldehyde. Scand J Work Environ Health 39: 618–630. 10.5271/sjweh.3358.23525098
NAC/AEGL (National Advisory Committee for Acute Exposure Guideline Levels for Hazardous Substances). (2008). Interim acute exposure guideline levels (AEGLs) for formaldehyde (CAS Reg. No. 50-00-0). Washington, DC: National Advisory Committee for Acute Exposure Guideline Levels. https://www.epa.gov/sites/production/files/2014-07/documents/formaldehyde_tsd_interim_07_2008.v1_0.pdf.
Nadin, SB; Vargas-Roig, LM; Ciocca, DR. (2001). A silver staining method for single-cell gel assay. J Histochem Cytochem 49: 1183–1186. 10.1177/002215540104900912.11511687
Nakamura, J; Holley, DW; Kawamoto, T; Bultman, SJ. (2020). The failure of two major formaldehyde catabolism enzymes (ADH5 and ALDH2) leads to partial synthetic lethality in C57BL/6 mice. Genes Environ 42: 21. 10.1186/s41021-020-00160-4.32514323
Nalivaiko, E; De Pasquale, CG; Blessing, WW. (2003). Electrocardiographic changes associated with the nasopharyngeal reflex in conscious rabbits: Vago-sympathetic co-activation. Auton Neurosci 105: 101–104. 10.1016/s1566-0702(03)00048-1.12798206
NASEM (National Academies of Sciences, Engineering, and Medicine). (2023). Review of EPA’s 2022 Draft Formaldehyde Assessment. Washington, DC. https://nap.nationalacademies.org/catalog/27153/review-of-epas-2022-draft-formaldehyde-assessment.
Natarajan, AT; Darroudi, F; Bussman, CJM; van Kesteren-Van Leeuwen, AC. (1983). Evaluation of the mutagenicity of formaldehyde in mammalian cytogenetic assays in vivo and vitro. Mutat Res 122: 355–360. 10.1016/0165-7992(83)90019-2.6656818
National Toxicology Program (NTP). (2005). Control data from NTP technical report series NOs. 210, 267, 272, 306, 311, 314, 329, 346, 363, 371, 375, 377, 379, 380, 386, 421, 437, 440, 447, 448, 450, 451, 453, 454, 461, 462, 466, 467, 468, 471, 472, 475, 482, 484, 486, 487, 490, 492, 499, 500, 507, 513, 515, 519 and control data from the wollastonite calcium silicates study. https://ntp.niehs.nih.gov/go/historical_controls.
Nazarparvar-Noshadi, M; Dolatabadi, JEN; Rasoulzadeh, Y; Mohammadian, Y; Shanehbandi, D. (2020). Apoptosis and DNA damage induced by silica nanoparticles and formaldehyde in human lung epithelial cells. Environ Sci Pollut Res Int 27: 18592–18601. 10.1007/s11356-020-08191-8.32198691
NCHS (National Center for Health Statistics). (2006). Chartbook on Trends in the Health of Americans. Hyattsville, MD: National Center for Health Statistics, Centers for Disease Control and Prevention. http://www.cdc.gov/nchs/data/hus/hus06.pdf.
NCHS (National Center for Health Statistics). (2009). Deaths: Final data for 2006. Natl Vital Stat Rep 57: 1–134.
Neamtiu, IA; Lin, S; Chen, ML; Roba, C; Csobod, E, va; Gurzau, ES. (2019). Assessment of formaldehyde levels in relation to respiratory and allergic symptoms in children from Alba County schools, Romania. Environ Monit Assess 191: 591. 10.1007/s10661-019-7768-6.31446497
NEG (Nordic Expert Group for Criteria Documentation of Health Risks from Chemicals). (2003). Formaldehyde. Stockholm, Sweden: National Institute for Working Life. http://ebib.arbetslivsinstitutet.se/ah/2003/ah2003_11.pdf.
Neghab, M; Delikhoon, M; Norouzian Baghani, A; Hassanzadeh, J. (2017). Exposure to Cooking Fumes and Acute Reversible Decrement in Lung Functional Capacity. Int J Occup Environ Med 8: 207–216. 10.15171/ijoem.2017.1100.28970595
Neghab, M; Soltanzadeh, A; Choobineh, A. (2011). Respiratory morbidity induced by occupational inhalation exposure to formaldehyde. Ind Health 49: 89–94. 10.2486/indhealth.MS1197.20823630
Neuss, S; Moepps, B; Speit, G. (2010a). Exposure of human nasal epithelial cells to formaldehyde does not lead to DNA damage in lymphocytes after co-cultivation. Mutagenesis 25: 359–364. 10.1093/mutage/geq013.20299426
Neuss, S; Speit, G. (2008). Further characterization of the genotoxicity of formaldehyde in vitro by the sister chromatid exchange test and co-cultivation experiments. Mutagenesis 23: 355–357. 10.1093/mutage/gen025.18477654
Neuss, S; Zeller, J; Ma-Hock, L; Speit, G. (2010b). Inhalation of formaldehyde does not induce genotoxic effects in broncho-alveolar lavage (BAL) cells of rats. Mutat Res Genet Toxicol Environ Mutagen 695: 61–68. 10.1016/j.mrgentox.2009.12.001.
Nielsen, GD. (1991). Mechanisms of activation of the sensory irritant receptor by airborne chemicals [Review]. Crit Rev Toxicol 21: 183–208. 10.3109/10408449109089879.2039594
Nielsen, GD; Hougaard, KS; Larsen, ST; Hammer, M; Wolkoff, P; Clausen, PA; Wilkins, CK; Alarie, Y. (1999). Acute airway effects of formaldehyde and ozone in BALB/c mice. Hum Exp Toxicol 18: 400–409. 10.1191/096032799678840246.10413245
Nielsen, GD; Wolkoff, P; Alarie, Y. (2007). Sensory irritation: risk assessment approaches [Review]. Regul Toxicol Pharmacol 48: 6–18. 10.1016/j.yrtph.2006.11.005.17241726
Niinimaa, V; Cole, P; Mintz, S; Shephard, RJ. (1981). Oronasal distribution of respiratory airflow. Respir Physiol 43: 69–75. 10.1016/0034-5687(81)90089-X.7244427
Nilsson, JA; Hedberg, JJ; Vondracek, M; Staab, CA; Hansson, A; Hoog, JO; Grafstrom, RC. (2004). Alcohol dehydrogenase 3 transcription associates with proliferation of human oral keratinocytes. Cell Mol Life Sci 61: 610–617. 10.1007/s00018-003-3433-9.15004699
NIOSH (National Institute for Occupational Safety and Health). (1977). NIOSH manual of analytical methods: Second edition, volume 2, part II: Standards completion program validated methods. In NIOSH manual of analytical methods: Second edition, volume 2, part II: Standards completion program validated methods. (DHEW (NIOSH) Publication No. 77-157-B). Cincinnati, OH.
NIOSH (National Institute for Occupational Safety and Health). (1994). Formaldehyde method 3500. In NIOSH manual of analytical methods (4th ed., pp. 3500–3501 - 3500–3504). (DHHS/NIOSH Pub. 84-100). Washington, DC. https://www.cdc.gov/niosh/docs/2003-154/pdfs/3500.pdf.
NLM (National Library of Medicine). (2019). PubChem: Hazardous Substance Data Bank: Formaldehyde, 50-00-0. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/712#source=HSDB (accessed
Nockher, WA; Renz, H. (2006). Neurotrophins and asthma: Novel insight into neuroimmune interaction. J Allergy Clin Immunol 117: 67–71. 10.1016/j.jaci.2005.08.029.16387586
Norback, D; Bjornsson, E; Janson, C; Widstrom, J; Boman, G. (1995). Asthmatic symptoms and volatile organic compounds, formaldehyde, and carbon dioxide in dwellings. Occup Environ Med 52: 388–395. 10.1136/oem.52.6.388.7627316
Norbäck, D; Hashim, JH; Hashim, Z; Ali, F. (2017). Volatile organic compounds (VOC), formaldehyde and nitrogen dioxide (NO2) in schools in Johor Bahru, Malaysia: Associations with rhinitis, ocular, throat and dermal symptoms, headache and fatigue. Sci Total Environ 592: 153–160. 10.1016/j.scitotenv.2017.02.215.28319702
Norback, D; Walinder, R; Wieslander, G; Smedje, G; Erwall, C; Venge, P. (2000). Indoor air pollutants in schools: nasal patency and biomarkers in nasal lavage. Allergy 55: 163–170. 10.1034/j.1398-9995.2000.00353.x.10726731
Norsted, SW; Kozinetz, CA; Annegers, JF. (1985). Formaldehyde complaint investigations in mobile homes by the Texas Department of Health. Environ Res 37: 93–100. 10.1016/0013-9351(85)90052-0.3996345
Novak, JP; Fedoroff, S. (1996). Cell cycle time of murine neopallial cells in vitro. J Neurosci Res 45: 75–84. 10.1002/(SICI)1097-4547(19960701)45:1<75::AID-JNR7>3.0.CO;2-E.8811514
NRC (National Research Council). (1988). Health risks of radon and other internally deposited alpha emitters: BEIR IV. Washington, DC. http://books.nap.edu/openbook.php?record_id=1026&page=R1.
NRC (National Research Council). (2011). Review of the Environmental Protection Agency’s draft IRIS assessment of formaldehyde (pp. 1–194). Washington, DC: The National Academies Press. 10.17226/13142.
NRC (National Research Council). (2014). Review of the Formaldehyde Assessment in the National Toxicology Program 12th Report on Carcinogens. Washington (DC): National Academies Press (US). 10.17226/18948.
NTP (National Toxicology Program). (2010). Final report on carcinogens. Background document for formaldehyde [NTP] (pp. i–512).
NTP (National Toxicology Program). (2011a). Report on carcinogens. Twelfth Edition, 2011 (12th ed., pp. 507). (NTP TR 581 126). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2011111646.xhtml.
NTP (National Toxicology Program). (2011b). Twelfth Report On Carcinogens, 2011. [CBRNIAC-1953235] (pp. 499). https://www.dtic.mil/DOAC/document?document=CBRNIAC-1953235&collection=ac-tems&contentType=PDF&citationFormat=1f.
NTP (National Toxicology Program). (2014). 13th Report on carcinogens [NTP]. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service.
Nunn, AJ; Craigen, AA; Darbyshire, JH; Venables, KM; Taylor, AJN. (1990). Six year follow up of lung function in men occupationally exposed to formaldehyde. Br J Ind Med 47: 747–752. 10.1136/oem.47.11.747.2245186
O’Connor, PM; Fox, BW. (1987). Comparative studies of DNA cross-linking reactions following methylene dimethanesulphonate and its hydrolytic product, formaldehyde. Cancer Chemother Pharmacol 19: 11–15. 10.1007/BF00296247.3815720
O’Connor, TM; O’Halloran, DJ; Shanahan, F. (2000). The stress response and the hypothalamic-pituitary-adrenal axis: from molecule to melancholia [Review]. QJM 93: 323–333.10873181
O’Donnell, R; Breen, D; Wilson, S; Djukanovic, R. (2006). Inflammatory cells in the airways in COPD [Review]. Thorax 61: 448–454. 10.1136/thx.2004.024463.16648353
O’Donovan, MR; Mee, CD. (1993). Formaldehyde is a bacterial mutagen in a range of Salmonella and Escherichia indicator strains. Mutagenesis 8: 577–581. 10.1093/mutage/8.6.577.8133788
Obe, G; Beek, B. (1979). Mutagenic activity of aldehydes. Drug Alcohol Depend 4: 91–94. 10.1016/0376-8716(79)90044-9.574448
Odeigah, PGC. (1997). Sperm head abnormalities and dominant lethal effects of formaldehyde in albino rats. Mutat Res Genet Toxicol Environ Mutagen 389: 141–148. 10.1016/S1383-5718(96)00136-2.
Odkvist, LM; Edling, C; Hellquist, H. (1985). Influence of vapours on the nasal mucosa among industry workers. Rhinology 23: 121–127.4035241
OECD (Organisation for Economic Co-operation and Development). (2009). Series on testing and assesment: Number 39. Guidance document on acute inhalation toxicity testing [OECD SIDS]. (ENV/JM/MONO(2009)28; JT03268144). Paris, Fr. http://search.oecd.org/officialdocuments/displaydocumentpdf/?cote=env/jm/mono%282009%2928&doclanguage=en.
Oerstavik, D; Hongslo, JK. (1985). Mutagenicity of endodontic sealers. Biomaterials 6: 129–132.4005357
Offermann, FJ; Robertson, J; Springer, D; Brennan, S; Woo, T. (2008). Window usage, ventilation, and formaldehyde concentrations in new california homes: Summer field sessions. Paper presented at ASHRAE IAQ 2007 Baltimore, MD.
Ohmichi, K; Komiyama, M; Matsuno, Y; Sawabe, Y; Miyaso, H; Fukata, H; Ohmichi, M; Kadota, T; Nomura, F; Moria, C. (2006). Relationship between exposure to formaldehyde and immunoglobulin E (IgE) production during the gross anatomy laboratory. J Health Sci 52: 642–647. 10.1248/jhs.52.642.
Ohta, T; Watanabe-Akanuma, M; Tokishita, S; Yamagata, H. (1999). Mutation spectra of chemical mutagens determined by Lac+ reversion assay with Escherichia coli WP3101P-WP3106P tester strains. Mutat Res Genet Toxicol Environ Mutagen 440: 59–74.
Ohtsuka, R; Shuto, Y; Fujie, H; Takeda, M; Harada, T; Itagaki, S. (1997). Response of respiratory epithelium of BN and F344 rats to formaldehyde inhalation. Exp Anim 46: 279–286. 10.1538/expanim.46.279.9353635
Ohtsuka, R; Shutoh, Y; Fujie, H; Yamaguchi, S; Takeda, M; Harada, T; Doi, K. (2003). Rat strain difference in histology and expression of Th1- and Th2-related cytokines in nasal mucosa after short-term formaldehyde inhalation. Exp Toxicol Pathol 54: 287–291. 10.1078/0940-2993-00266.12710711
Olin, KL; Cherr, GN; Rifkin, E; Keen, CL. (1996). The effects of some redox-active metals and reactive aldehydes on DNA-protein cross-links in vitro. Toxicology 110: 1–8. 10.1016/0300-483X(96)03318-5.8658550
Olive, PL; Banath, JP. (2006). The comet assay: A method to measure DNA damage in individual cells. Nat Protoc 1: 23–29. 10.1038/nprot.2006.5.17406208
Ollerenshaw, SL; Jarvis, D; Sullivan, CE; Woolcock, AJ. (1991). Substance P immunoreactive nerves in airways from asthmatics and nonasthmatics. Eur Respir J 4: 673–682.1716217
Olsen, JH; Asnaes, S. (1986a). Formaldehyde and risk of squamous cell carcinoma of the sino nasal cavities. Occup Environ Med 43: 769–774.
Olsen, JH; Asnaes, S. (1986b). Formaldehyde and the risk of squamous cell carcinoma of the sinonasal cavities. Br J Ind Med 43: 769–744. 10.1136/oem.43.11.769.3790457
Olsen, JH; Dossing, M. (1982). Formaldehyde induced symptoms in day care centers. AIHA J 43: 366–370. 10.1080/15298668291409866.
Olsen, JH; Jensen, SP; Hink, M; Faurbo, K; Breum, NO; Jensen, ON. (1984). Occupational formaldehyde exposure and increased nasal cancer risk in man. Int J Cancer 34: 639–644. 10.1002/ijc.2910340509.6500742
Orsiere, T; Sari-Minodier, I; Iarmarcovai, G; Botta, A. (2006). Genotoxic risk assessment of pathology and anatomy laboratory workers exposed to formaldehyde by use of personal air sampling and analysis of DNA damage in peripheral lymphocytes. Mutat Res Genet Toxicol Environ Mutagen 605: 30–41. 10.1016/j.mrgentox.2006.01.006.
Orstavik, D; Hongslo, JK. (1985). Mutagenicity of endodontic sealers. Biomaterials 6: 129–132. 10.1016/0142-9612(85)90076-6.4005357
Ostojić, L; Bradarić, A; Mise, K; Ostojić, Z; Lovrić, J; Petrović, P; Ujević, A; Erceg, M; Janković, S; Tocilj, J. (2006). Pulmonary function in persons who are professionally exposed to formaldehyde fumes. Coll Antropol 30: 507–511.17058515
Ott, MG; Teta, J; Greenberg, HL. (1989). Lymphatic and hematopoietic tissue cancer in a chemical manufacturing environment. Am J Ind Med 16: 631–644. 10.1002/ajim.4700160603.2556914
Overton, JH; Kimbell, JS; Miller, FJ. (2001). Dosimetry modeling of inhaled formaldehyde: The human respiratory tract. Toxicol Sci 64: 122–134. 10.1093/toxsci/64.1.122.11606808
Ozen, OA; Akpolat, N; Songur, A; Kuş, I; Zararsiz, I; Ozaçmak, VH; Sarsilmaz, M. (2005). Effect of formaldehyde inhalation on Hsp70 in seminiferous tubules of rat testes: An immunohistochemical study. Toxicol Ind Health 21: 249–254. 10.1191/0748233705th235oa.16463957
Ozen, OA; Kus, MA; Kus, I; Alkoc, OA; Songur, A. (2008). Protective effects of melatonin against formaldehyde-induced oxidative damage and apoptosis in rat testes: An immunohistochemical and biochemical study. Sys Biol Reprod Med 54: 169–176. 10.1080/19396360802422402.
Ozen, OA; Songue, A; Sars, M; Yaman, M; Kus, I. (2003a). Changes of zinc, copper, and iron levels in the lung of male rats after subacute (4-week) and subchronic (13-week) exposure to formaldehyde. J Trace Elem Exp Med 16: 67–74. 10.1002/jtra.10026.
Ozen, OA; Songur, A; Sarsilmaz, M; Yaman, M; Kuş, I. (2003b). Zinc, copper and iron concentrations in cerebral cortex of male rats exposed to formaldehyde inhalation. J Trace Elem Med Biol 17: 207–209. 10.1016/S0946-672X(03)80027-5.14968934
Ozen, OA; Yaman, M; Sarsilmaz, M; Songur, A; Kus, I. (2002). Testicular zinc, copper and iron concentrations in male rats exposed to subacute and subchronic formaldehyde gas inhalation. J Trace Elem Med Biol 16: 119–122. 10.1016/S0946-672X(02)80038-4.12195726
Pala, M; Ugolini, D; Ceppi, M; Rizzo, F; Maiorana, L; Bolognesi, C; Schilirò, T; Gilli, G; Bigatti, P; Bono, R; Vecchio, D. (2008). Occupational exposure to formaldehyde and biological monitoring of Research Institute workers. Cancer Detect Prev 32: 2008. 10.1016/j.cdp.2008.05.003.
Palczynski, C; Krakowiak, A; Hanke, W; Walusiak, J; Gorski, P. (1999). Indoor formaldehyde exposure and airway allergic diseases. Int Rev Allergol Clin Immunol 5: 65–69.
Pandey, MK. (2013). Molecular Basis for Downregulation of C5a-Mediated Inflammation by IgG1 Immune Complexes in Allergy and Asthma. Curr Allergy Asthma Rep 13: 596–606. 10.1007/s11882-013-0387-3.24013944
Park, J; Yang, H; Song, MK; Kim, D; Lee, K. (2020). Formaldehyde exposure induces regulatory T cell-mediated immunosuppression via calcineurin-NFAT signalling pathway. Sci Rep 10: 17023. 10.1038/s41598-020-72502-9.33046725
Partanen, T; Kauppinen, T; Hernberg, S; Nickels, J; Luukkonen, R; Hakulinen, T; Pukkala, E. (1990). Formaldehyde exposure and respiratory cancer among woodworkers - an update. Scand J Work Environ Health 16: 394–400. 10.5271/sjweh.1766.2284589
Parthasarathy, S; Maddalena, RL; Russell, ML; Apte, MG. (2011). Effect of Temperature and Humidity on Formaldehyde Emissions in Temporary Housing Units. J Air Waste Manag Assoc 61: 689–695. 10.3155/1047-3289.61.6.689.21751584
Paul, WE; Brown, M; Hornbeck, P; Mizuguchi, J; Ohara, J; Rabin, E; Snapper, C; Tsang, W. (1987). Regulation of B-lymphocyte activation, proliferation, and differentiation [Review]. Ann N Y Acad Sci 505: 82–89. 10.1111/j.1749-6632.1987.tb51284.x.2825578
Pauluhn, J. (1998). Hazard identification and risk assessment of pyrethroids in the indoor environment. Appl Occup Environ Hyg 13: 469–478.
Pauluhn, J. (2008). Inhalation toxicology: Methodological and regulatory challenges. Exp Toxicol Pathol 60: 111–124. 10.1016/j.etp.2008.01.013.18468874
Pauluhn, J. (2018). Upper respiratory tract nociceptor stimulation and stress response following acute and repeated Cyfluthrin inhalation in normal and pregnant rats: Physiological rat-specific adaptions can easily be misunderstood as adversities [Review]. Toxicol Lett 282: 8–24. 10.1016/j.toxlet.2017.10.003.29017960
Payani, S; Mamatha, C; Chandraprakash, C; Bhaskar, M. (2019). Protective role of (Bronco-T) against formaldehyde induced antioxidant, oxidative and histopathological changes in lung of male Wistar rats. Toxicol Rep 6: 718–726. 10.1016/j.toxrep.2019.07.002.31388499
Pazdrak, K; Gorski, P; Krakowiak, A; Ruta, U. (1993). Changes in nasal lavage fluid due to formaldehyde inhalation. Int Arch Occup Environ Health 64: 515–519. 10.1007/BF00381101.8482593
Peddada, SD; Dinse, GE; Kissling, GE. (2007). Incorporating historical control data when comparing tumor incidence rates. J Am Stat Assoc 102: 1212–1220. 10.1198/016214506000001356.20396669
Peddada, SD; Kissling, GE. (2006). A survival-adjusted quantal-response test for analysis of tumor incidence rates in animal carcinogenicity studies. Environ Health Perspect 114: 537–541. 10.1289/ehp.8590.16581542
Peng, G; Yang, X; Zhao, W; Sun, J; Cao, Y; Xu, Q; Yuan, J; Ding, S. (2006). Gaseous formaldehyde-induced DNA-protein crosslinks in liver, kidney and testicle of Kunming mice. Life Science Journal 3: 82–87.
Percy, C; Stanek, E, III; Gloeckler, L. (1981). Accuracy of cancer death certificates and its effect on cancer mortality statistics. Am J Public Health 71: 242–250. 10.2105/AJPH.71.3.242.7468855
Percy, CL; Miller, BA; Gloeckler Ries, LA. (1990). Effect of changes in cancer classification and the accuracy of cancer death certificates on trends in cancer mortality. Ann N Y Acad Sci 609: 87–99. 10.1111/j.1749-6632.1990.tb32059.x.2264660
Perry, P; Wolff, S. (1974). New Giemsa method for the differential staining of sister chromatids. Nature 251: 156–158.4138930
Persoz, C; Achard, S; Leleu, C; Momas, I; Seta, N. (2010). An in vitro model to evaluate the inflammatory response after gaseous formaldehyde exposure of lung epithelial cells. Toxicol Lett 195: 99–105. 10.1016/j.toxlet.2010.03.003.20226236
Persoz, C; Achard, S; Momas, I; Seta, N. (2012). Inflammatory response modulation of airway epithelial cells exposed to formaldehyde. Toxicol Lett 211: 159–163. 10.1016/j.toxlet.2012.03.799.22484645
Persoz, C; Leleu, C; Achard, S; Fasseu, M; Menotti, J; Meneceur, P; Momas, I; Derouin, F; Seta, N. (2011). Sequential air-liquid exposure of human respiratory cells to chemical and biological pollutants. Toxicol Lett 207: 53–59. 10.1016/j.toxlet.2011.07.028.21840384
Pesch, B; Pierl, CB; Gebel, M; Gross, I; Becker, D; Johnen, G; Rihs, HP; Donhuijsen, K; Lepentsiotis, V; Meier, M; Schulze, J; Brüning, T. (2008). Occupational risks for adenocarcinoma of the nasal cavity and paranasal sinuses in the German wood industry. Occup Environ Med 65: 191–196. 10.1136/oem.2007.033886.17881467
Peteffi, GP; Basso da Silva, L; Antunes, MV; Wilhelm, C; Valandro, ET; Glaeser, J; Kaefer, D; Linden, R. (2015). Evaluation of genotoxicity in workers exposed to low levels of formaldehyde in a furniture manufacturing facility. Toxicol Ind Health 32: 1763–1773. 10.1177/0748233715584250.25971585
Peters, TL; Kamel, F; Lundholm, C; Feychting, M; Weibull, CE; Sandler, DP; Wiebert, P; Sparén, P; Ye, W; Fang, F. (2017). Occupational exposures and the risk of amyotrophic lateral sclerosis. Occup Environ Med 74: 87–92. 10.1136/oemed-2016-103700.27418175
Pickrell, JA; Griffis, LC; Mokler, BV; Kanapilly, GM; Hobbs, CH. (1984). Formaldehyde release from selected consumer products: influence of chamber loading, multiple products, relative humidity, and temperature. Environ Sci Technol 18: 682–686. 10.1021/es00127a009.
Pickrell, JA; Mokler, BV; Griffis, LC; Hobbs, CH. (1983). Formaldehyde release rate coefficients from selected consumer products. Environ Sci Technol 17: 753–757. 10.1021/es00118a012.22283133
Pierce, JS; Abelmann, A; Spicer, LJ; Adams, RE; Glynn, ME; Neier, K; Finley, BL; Gaffney, SH. (2011). Characterization of formaldehyde exposure resulting from the use of four professional hair straightening products. J Occup Environ Hyg 8: 686–699. 10.1080/15459624.2011.626259.22035353
Pinkerton, LE; Hein, MJ; Meyers, A; Kamel, F. (2013). Assessment of ALS mortality in a cohort of formaldehyde-exposed garment workers. 14: 353–355. 10.3109/21678421.2013.778284.
Pinkerton, LE; Hein, MJ; Stayner, LT. (2004). Mortality among a cohort of garment workers exposed to formaldehyde: an update. Occup Environ Med 61: 193–200. 10.1136/oem.2003.007476.14985513
Pira, E; Romano, C; Verga, F; La Vecchia, C. (2014). Mortality from lymphohematopoietic neoplasms and other causes in a cohort of laminated plastic workers exposed to formaldehyde. Cancer Causes Control 25: 1343–1349. 10.1007/s10552-014-0440-0.25053406
Pitarque, M; Vaglenov, A; Nosko, M; Hirvonen, A; Norppa, H; Creus, A; Marcos, R. (1999). Evaluation of DNA damage by the Comet assay in shoe workers exposed to toluene and other organic solvents. Mutat Res 441: 115–127. 10.1016/S1383-5718(99)00042-X.10224328
Pitten, FA; Kramer, A; Herrmann, K; Bremer, J; Koch, S. (2000). Formaldehyde neurotoxicity in animal experiments. Pathol Res Pract 196: 193–198. 10.1016/S0344-0338(00)80100-4.10729924
Plesner, BH; Hansen, K. (1983). Formaldehyde and hexamethylenetetramine in Styles’ cell transformation assay. Carcinogenesis 4: 457–459. 10.1093/carcin/4.4.457.6839418
Pontel, LB; Rosado, IV; Burgos-Barragan, G; Garaycoechea, JI; Yu, R; Arends, MJ; Chandrasekaran, G; Broecker, V; Wei, W; Liu, L; Swenberg, JA; Crossan, GP; Patel, KJ. (2015). Endogenous Formaldehyde Is a Hematopoietic Stem Cell Genotoxin and Metabolic Carcinogen. Mol Cell 60: 177–188. 10.1016/j.molcel.2015.08.020.26412304
Portier, CJ; Bailer, AJ. (1989). Testing for increased carcinogenicity using a survival-adjusted quantal response test. Fundam Appl Toxicol 12: 731–737. 10.1016/0272-0590(89)90004-3.2744275
Pottern, LM; Heineman, EF; Olsen, JH; Raffn, E; Blair, A. (1992). Multiple myeloma among Danish women: Employment history and workplace exposures. Cancer Causes Control 3: 427–432. 10.1007/BF00051355.1525323
Pourmahabadian, M; Azam, K; Ghasemkhani, M. (2006). Pulmonary function study between formaldehyde exposed and non-exposed staffs at some of the Tehran educational hospitals. Journal of Medical Sciences 6: 621–625. 10.3923/jms.2006.621.625.
Priha, E; Liesivuori, J; Santa, H; Laatikainen, R. (1996). Reactions of hydrated formaldehyde in nasal mucus. Chemosphere 32: 1077–1082. 10.1016/0045-6535(96)00015-X.8920592
Priha, E; Pennanen, S; Rantio, T; Uitti, J; Liesivuori, J. (2004). Exposure to and acute effects of medium-density fiber board dust. J Occup Environ Hyg 1: 738–744. 10.1080/15459620490520774.15673094
Pross, HF; Day, JH; Clark, RH; Lees, RE. (1987). Immunologic studies of subjects with asthma exposed to formaldehyde and urea-formaldehyde foam insulation (UFFI) off products. J Allergy Clin Immunol 79: 797–810. 10.1016/0091-6749(87)90213-2.2437172
Proud, D; Leigh, R. (2011). Epithelial cells and airway diseases [Review]. Immunol Rev 242: 186–204. 10.1111/j.1600-065X.2011.01033.x.21682746
Pushkina, NN; Gofmekler, VA; Klevtsova, GN. (1968). [Changes in ascorbic and nucleic acid concentration under the influence of benzene and formaldehyde]. Biull Eksp Biol Med 66: 51–53.
Qiao, Y; Li, B; Yang, G; Yao, H; Yang, J; Liu, D; Yan, Y; Sigsgaard, T; Yang, X. (2009). Irritant and adjuvant effects of gaseous formaldehyde on the ovalbumin-induced hyperresponsiveness and inflammation in a rat model. Inhal Toxicol 21: 1200–1207. 10.3109/08958370902806159.19827972
Quackenboss, JJ; Lebowitz, MD; Hayes, C. (1989a). Epidemiological study of respiratory responses to indoor/outdoor air quality. Environ Int 15: 493–502. 10.1016/0160-4120(89)90067-6.
Quackenboss, JJ; Lebowitz, MD; Michaud, JP; Bronnimann, D. (1989b). Formaldehyde exposure and acute health effects study. Environ Int 15: 169–176. 10.1016/0160-4120(89)90023-8.
Quarcoo, D; Schulte-Herbrüggen, O; Lommatzsch, M; Schierhorn, K; Hoyle, GW; Renz, H; Braun, A. (2004). Nerve growth factor induces increased airway inflammation via a neuropeptide-dependent mechanism in a transgenic animal model of allergic airway inflammation. Clin Exp Allergy 34: 1146–1151. 10.1111/j.1365-2222.2004.01993.x.15248864
Que, LG; Liu, L; Yan, Y; Whitehead, GS; Gavett, SH; Schwartz, DA; Stamler, JS. (2005). Protection from experimental asthma by an endogenous bronchodilator. Science 308: 1618–1621. 10.1126/science.1108228.15919956
Quievryn, G; Zhitkovich, A. (2000). Loss of DNA-protein crosslinks from formaldehyde-exposed cells occurs through spontaneous hydrolysis and an active repair process linked to proteosome function. Carcinogenesis 21: 1573–1580. 10.1093/carcin/21.8.1573.10910961
Raaschou-Nielsen, O; Hermansen, MN; Loland, L; Buchvald, F; Pipper, CB; Sørensen, M; Loft, S; Bisgaard, H. (2010). Long-term exposure to indoor air pollution and wheezing symptoms in infants. Indoor Air 20: 159–167. 10.1111/j.1600-0668.2009.00635.x.20028431
Ragan, DL; Boreiko, CJ. (1981). Initiation of C3H/10T1/2 cell transformation by formaldehyde. Cancer Lett 13: 325–331. 10.1016/0304-3835(81)90061-6.7306959
Rager, JE; Moeller, BC; Doyle-Eisele, M; Kracko, D; Swenberg, JA; Fry, RC. (2013). Formaldehyde and epigenetic alterations: microRNA changes in the nasal epithelium of nonhuman primates. Environ Health Perspect 121: 339–344. 10.1289/ehp.1205582.23322811
Rager, JE; Moeller, BC; Miller, SK; Kracko, D; Doyle-Eisele, M; Swenberg, JA; Fry, RC. (2014). Formaldehyde-Associated Changes in microRNAs: Tissue and Temporal Specificity in the Rat Nose, White Blood Cells, and Bone Marrow. Toxicol Sci 138: 36–46. 10.1093/toxsci/kft267.24304932
Rager, JE; Smeester, L; Jaspers, I; Sexton, KG; Fry, RC. (2011). Epigenetic changes induced by air toxics: formaldehyde exposure alters miRNA expression profiles in human lung cells. Environ Health Perspect 119: 494–500. 10.1289/ehp.1002614.21147603
Rao, GN; Piegorsch, WW; Haseman, JK. (1987). Influence of body weight on the incidence of spontaneous neoplasms in rats and mice of long-term studies. Am J Clin Nutr 45: 252–260.3799516
Ratnayake, WE. (1968). Tests for an effect of the Y-chromosome on the mutagenic action of formaldehyde and x-rays in Drosophila melanogaster. Genet Res 12: 65–69. 10.1017/S0016672300011629.5713812
Ratnayake, WE. (1970). Studies on the relationship between induced crossing-over and mutation in Drosophila melanogaster. Mutat Res 9: 71–83. 10.1016/0027-5107(70)90071-0.5410811
Ravault, C; Kauffmann, F. (2001). Validity of the IUATLD (1986) questionnaire in the EGEA study. Int J Tuberc Lung Dis 5: 191–196.11258514
Reader, JR; Tepper, JS; Schelegle, ES; Aldrich, MC; Putney, LF; Pfeiffer, JW; Hyde, DM. (2003). Pathogenesis of mucous cell metaplasia in a murine asthma model. Am J Pathol 162: 2069–2078. 10.1016/S0002-9440(10)64338-6.12759261
Recio, L; Sisk, S; Pluta, L; Bermudez, E; Gross, EA; Chen, Z; Morgan, K; Walker, C. (1992). p53 mutations in formaldehyde-induced nasal squamous cell carcinomas in rats. Cancer Res 52: 6113–6116.1394239
Reiss, R; Ryan, PB; Koutrakis, P; Tibbetts, SJ. (1995). Ozone reactive chemistry on interior latex paint. Environ Sci Technol 29: 1906–1912. 10.1021/es00008a007.22191336
Ren, X; Ji, Z; Mchale, CM; Yuh, J; Bersonda, J; Tang, M; Smith, MT; Zhang, L. (2013). The impact of FANCD2 deficiency on formaldehyde-induced toxicity in human lymphoblastoid cell lines. Arch Toxicol 87: 189–196. 10.1007/s00204-012-0911-6.22872141
Reuzel, PGJ; Wilmer, JWG, M; Woutersen, RA; Zwart, A; Rombout, PJA; Feron, VJ. (1990). Interactive effects of ozone and formaldehyde on the nasal respiratory lining epithelium in rats. J Toxicol Environ Health 29: 279–292. 10.1080/15287399009531391.2313740
Ricciardolo, FLM; Nijkamp, F; De Rose, V; Folkerts, G. (2008). The guinea pig as an animal model for asthma. Curr Drug Targets 9: 452–465. 10.2174/138945008784533534.18537584
Riedel, F; Hasenauer, E; Barth, PJ; Koziorowski, A; Rieger, CHL. (1996). Formaldehyde exposure enhances inhalative allergic sensitization in the guinea pig. Allergy 51: 94–99. 10.1111/j.1398-9995.1996.tb00041.x.8738514
Riess, U; Tegtbur, U; Fauck, C; Fuhrmann, F; Markewitz, D; Salthammer, T. (2010). Experimental setup and analytical methods for the non-invasive determination of volatile organic compounds, formaldehyde and NOx in exhaled human breath. Anal Chim Acta 669: 53–62. 10.1016/j.aca.2010.04.049.20510903
Ritchie, IM; Lehnen, RG. (1985). An analysis of formaldehyde concentrations in mobile and conventional homes. J Environ Health 47: 300–305.
Ritchie, IM; Lehnen, RG. (1987). Formaldehyde-related health complaints of residents living in mobile and conventional homes. Am J Public Health 77: 323–328. 10.2105/ajph.77.3.323.3812839
Roberts, AL; Johnson, NJ; Cudkowicz, ME; Eum, KD; Weisskopf, MG. (2016). Job-related formaldehyde exposure and ALS mortality in the USA [Letter]. J Neurol Neurosurg Psychiatry 87: 786–788. 10.1136/jnnp-2015-310750.26169306
Robinson, CF; Fowler, D; Brown, DP; Lemen, RA. (1987). Plywood mill workers’ mortality patterns 1945 1977 (revised March 1987). (NIOSH/00197140). Cincinnati, OH: NIOSH.
Roda, C; Kousignian, I; Guihenneuc-Jouyaux, C; Dassonville, C; Nicolis, I; Just, J; Momas, I. (2011). Formaldehyde exposure and lower respiratory infections in infants: findings from the PARIS cohort study. Environ Health Perspect 119: 1653–1658. 10.1289/ehp.1003222.21810553
Rodrigo, R; Prat, H; Passalacqua, W; Araya, J; Guichard, C; Bächler, JP. (2007). Relationship between oxidative stress and essential hypertension. Hypertens Res 30: 1159–1167. 10.1291/hypres.30.1159.18344620
Roemer, E; Anton, HJ; Kindt, R. (1993). Cell proliferation in the respiratory tract of the rat after acute inhalation of formaldehyde or acrolein. J Appl Toxicol 13: 103–107. 10.1002/jat.2550130206.8486908
Roma-Torres, J; Teixeira, JP; Silva, S; Laffon, B; Cunha, LM; Méndez, J; Mayan, O. (2006). Evaluation of genotoxicity in a group of workers from a petroleum refinery aromatics plant. Mutat Res 604: 19–27. 10.1016/j.mrgentox.2005.12.005.16431152
Romanazzi, V; Pirro, V; Bellisario, V; Mengozzi, G; Peluso, M; Pazzi, M; Bugiani, M; Verlato, G; Bono, R. (2013). 15-F2t isoprostane as biomarker of oxidative stress induced by tobacco smoke and occupational exposure to formaldehyde in workers of plastic laminates. Sci Total Environ 442: 20–25. 10.1016/j.scitotenv.2012.10.057.23178760
Ross, WE; Mcmillan, DR; Ross, CF. (1981). Comparison of DNA damage by methylmelamines and formaldehyde. J Natl Cancer Inst 67: 217–221.6788992
Ross, WE; Shipley, N. (1980). Relationship between DNA damage and survival in formaldehyde-treated mouse cells. Mutat Res 79: 277–283. 10.1016/0165-1218(80)90075-0.7219432
Rossant, J; Cross, JC. (2001). Placental development: Lessons from mouse mutants [Review]. Nat Rev Genet 2: 538–548. 10.1038/35080570.11433360
Rothman, KJ; Boice, JD. (1979). Epidemiologic analysis with a programmable calculator. (NIH Publication No. 79-1649). Washington, D.C.: National Institutes of Health.
Rothman, N; Lan, Q; Smith, MT; Vermeulen, R; Zhang, L. (2017). Response to letter to the editor of Carcinogenesis by Pira et al., 2017 [Letter]. Carcinogenesis 38: 1253–1255. 10.1093/carcin/bgx111.29040449
Rotstein, J; Sarma, DS; Farber, E. (1986). Sequential alterations in growth control and cell dynamics of rat hepatocytes in early precancerous steps in hepatocarcinogenesis. Cancer Res 46: 2377–2385.3697980
Roush, GC; Walrath, J; Stayner, LT; Kaplan, SA; Flannery, JT; Blair, A. (1987). Nasopharyngeal cancer sinonasal cancer and occupations related to formaldehyde: A case-control study. J Natl Cancer Inst 79: 1221–1224.3480373
Rumchev, K; Spickett, J; Bulsara, M; Phillips, M; Stick, S. (2004). Association of domestic exposure to volatile organic compounds with asthma in young children. Thorax 59: 746–751. 10.1136/thx.2003.013680.15333849
Rumchev, KB; Spickett, JT; Bulsara, MK; Phillips, MR; Stick, SM. (2002). Domestic exposure to formaldehyde significantly increases the risk of asthma in young children. Eur Respir J 20: 403–408. 10.1183/09031936.02.00245002.12212974
Rusch, GM; Clary, JJ; Rinehart, WE; Bolte, HF. (1983). A 26-week inhalation toxicity study with formaldehyde in the monkey, rat, and hamster. Toxicol Appl Pharmacol 68: 329–343. 10.1016/0041-008X(83)90276-4.6857667
Rydén, E; Ekström, C; Hellmér, L; Bolcsfoldi, G. (2000). Comparison of the sensitivities of Salmonella typhimurium strains TA102 and TA2638A to 16 mutagens. Mutagenesis 15: 495–502.11077001
Saberi Hosnijeh, F; Christopher, Y; Peeters, P; Romieu, I; Xun, W; Riboli, E; Raaschou-Nielsen, O; Tjønneland, A; Becker, N; Nieters, A; Trichopoulou, A; Bamia, C; Orfanos, P; Oddone, E; Luján-Barroso, L; Dorronsoro, M; Navarro, C; Barricarte, A; Molina-Montes, E; Wareham, N; Vineis, P; Vermeulen, R. (2013). Occupation and risk of lymphoid and myeloid leukaemia in the European Prospective Investigation into Cancer and Nutrition (EPIC). Occup Environ Med 70: 464–470. 10.1136/oemed-2012-101135.23576671
Sadakane, K; Takano, H; Ichinose, T; Yanagisawa, R; Shibamoto, T. (2002). Formaldehyde enhances mite allergen-induced eosinophilic inflammation in the murine airway. J Environ Pathol Toxicol Oncol 21: 267–276.12435080
Sahin-Yilmaz, A; Naclerio, RM. (2011). Anatomy and physiology of the upper airway [Review]. Proc Am Thorac Soc 8: 31–39. 10.1513/pats.201007-050RN.21364219
Saillenfait, AM; Bonnet, P; de Ceaurriz, J. (1989). The effects of maternally inhaled formaldehyde on embryonal and foetal development in rats. Food Chem Toxicol 27: 545–548. 10.1016/0278-6915(89)90051-3.2792978
Saito, Y; Nishio, K; Yoshida, Y; Niki, E. (2005). Cytotoxic effect of formaldehyde with free radicals via increment of cellular reactive oxygen species. Toxicology 210: 235–245. 10.1016/j.tox.2005.02.006.15840437
Sakellaris, I; Saraga, D; Mandin, C; de Kluizenaar, Y; Fossati, S; Spinazzè, A; Cattaneo, A; Mihucz, V; Szigeti, T; de Oliveira Fernandes, E; Kalimeri, K; Mabilia, R; Carrer, P; Bartzis, J. (2020). Association of subjective health symptoms with indoor air quality in European office buildings: The OFFICAIR project. Indoor Air 31: 426–439. 10.1111/ina.12749.32966653
Saladino, AJ; Willey, JC; Lechner, JF; Grafstrom, RC; Laveck, M; Harris, CC. (1985). Effects of formaldehyde, acetaldehyde, benzoyl peroxide, and hydrogen peroxide on cultured normal human bronchial epithelial cells. Cancer Res 45: 2522–2526.3986791
Salas, MM; Hargreaves, KM; Akopian, AN. (2009). TRPA1-mediated responses in trigeminal sensory neurons: Interaction between TRPA1 and TRPV1. Eur J Neurosci 29: 1568–1578. 10.1111/j.1460-9568.2009.06702.x.19419422
Saldiva, PHN; Caldeira, MPR; Massad, E; Calheiros, DF; Cardoso, LMN; Bohm, GM; Saldiva, CD. (1985). Effects of formaldehyde and acetaldehyde inhalation on rat pulmonary mechanics. J Appl Toxicol 5: 288–292. 10.1002/jat.2550050505.4056306
Salonen, H; Pasanen, AL; Lappalainen, S; Riuttala, H; Tuomi, T; Pasanen, P; Back, B; Reijula, K. (2009). Volatile organic compounds and formaldehyde as explaining factors for sensory irritation in office environments. J Occup Environ Hyg 6: 239–247. 10.1080/15459620902735892.19184725
Salthammer, T; Mentese, S; Marutzky, R. (2010). Formaldehyde in the indoor environment. Chem Rev 110: 2536–2572. 10.1021/cr800399g.20067232
Sandel, M; Murphy, JS; Dixon, SL; Adgate, JL; Chew, GL; Dorevitch, S; Jacobs, DE. (2014). A side-by-side comparison of three allergen sampling methods in settled house dust. J Expo Sci Environ Epidemiol 24: 650–656. 10.1038/jes.2014.30.24802556
Sandikci, M; Eren, U; Kum, S. (2007a). Effects of formaldehyde and xylene on alpha-naphthyl acetate esterase positive T-lymphocytes in bronchus associated lymphoid tissue and peripheral blood in rats. Rev Med Vet 158: 297–301.
Sandikci, M; Eren, U; Kum, S. (2007b). Effects of formaldehyde and xylene on CD4- and CD8-positive T cells in bronchus-associated lymphoid tissue in rats. Toxicol Ind Health 23: 471–477. 10.1177/0748233708089025.18669168
Sandikci, M; Seyrek, K; Aksit, H; Kose, H. (2009). Inhalation of formaldehyde and xylene induces apoptotic cell death in the lung tissue. Toxicol Ind Health 25: 455–461. 10.1177/0748233709106824.19648215
Sanghani, PC; Stone, CL; Ray, BD; Pindel, EV; Hurley, TD; Bosron, WF. (2000). Kinetic mechanism of human glutathione-dependent formaldehyde dehydrogenase. Biochemistry 39: 10720–10729. 10.1021/bi9929711.10978156
Sanotskii, IV; Fomenko, VN; Sheveleva, GA; Sal’nikova, LS; Nakoriakova, MV. (1976). [Study of the effect of pregnancy on animal sensitivity to chemical agents]. Gig Tr Prof Zabol (1): 25–28.
Santovito, A; Cervella, P; Delpero, M. (2014). Chromosomal damage in peripheral blood lymphocytes from nurses occupationally exposed to chemicals. Hum Exp Toxicol 33: 897–903. 10.1177/0960327113512338.24275642
Santovito, A; Schilirò, T; Castellano, S; Cervella, P; Bigatti, MP; Gilli, G; Bono, R; Delpero, M. (2011). Combined analysis of chromosomal aberrations and glutathione S-transferase M1 and T1 polymorphisms in pathologists occupationally exposed to formaldehyde. Arch Toxicol 85: 1295–1302. 10.1007/s00204-011-0668-3.21360194
Saowakon, N; Ngernsoungnern, P; Watcharavitoon, P; Ngernsoungnern, A; Kosanlavit, R. (2015). Formaldehyde exposure in gross anatomy laboratory of Suranaree University of Technology: a comparison of area and personal sampling. Environ Sci Pollut Res Int 22: 19002–19012. 10.1007/s11356-015-5078-2.26233735
Sapmaz, E; Sapmaz, HI; Vardi, N; Tas, U; Sarsilmaz, M; Toplu, Y; Arici, A; Uysal, M. (2017). Harmful effects of formaldehyde and possible protective effect of Nigella sativa on the trachea of rats. Niger J Clin Pract 20: 523–529. 10.4103/1119-3077.183253.28513508
Sapmaz, HI; Sarsılmaz, M; Gödekmerdan, A; Ögetürk, M; Taş, U; Köse, E. (2015). Effects of formaldehyde inhalation on humoral immunity and protective effect of Nigella sativa oil: An experimental study. Toxicol Ind Health 32: 1564–1569. 10.1177/0748233714566294.25653037
Sapmaz, HI; Yildiz, A; Polat, A; Vardi, N; Kose, E; Tanbek, K; Cuglan, S. (2018). Protective efficacy of Nigella sativa oil against the harmful effects of formaldehyde on rat testicular tissue. 8: 548–553. 10.4103/2221-1691.245970.
Sari-Minodier, I; Orsière, T; Bellon, L; Pompili, J; Sapin, C; Botta, A. (2002). Cytogenetic monitoring of industrial radiographers using the micronucleus assay. Mutat Res 521: 37–46.12438002
Sari, DK; Kuwahara, S; Furuya, M; Tsukamoto, Y; Hori, H; Kunugita, N; Arashidani, K; Fujimaki, H; Sasaki, F. (2005). Hypothalamo-pituitary-adrenal gland axis in mice inhaling toluene prior to low-level long-term exposure to formaldehyde. J Vet Med Sci 67: 303–309. 10.1292/jvms.67.303.15805735
Sari, DK; Kuwahara, S; Tsukamoto, Y; Hori, H; Kunugita, N; Arashidani, K; Fujimaki, H; Sasaki, F. (2004). Effect of prolonged exposure to low concentrations of formaldehyde on the corticotropin releasing hormone neurons in the hypothalamus and adrenocorticotropic hormone cells in the pituitary gland in female mice. Brain Res 1013: 107–116. 10.1016/j.brainres.2004.03.070.15196973
Sarigiannis, DA; Karakitsios, SP; Gotti, A; Liakos, IL; Katsoyiannis, A. (2011). Exposure to major volatile organic compounds and carbonyls in European indoor environments and associated health risk [Review]. Environ Int 37: 743–765. 10.1016/j.envint.2011.01.005.21354626
Sarin, S; Undem, B; Sanico, A; Togias, A. (2006). The role of the nervous system in rhinitis. J Allergy Clin Immunol 118: 999–1016.17088122
Sarrif, AM; Krahn, DF; Donovan, SM; O’Neil, RM. (1997). Evaluation of hexamethylphosphoramide for gene mutations in Salmonella typhimurium using plate incorporation, preincubation, and suspension assays. Mutat Res 380: 167–177. 10.1016/S0027-5107(97)00134-6.9385397
Sarsilmaz, M; Kaplan, S; Songur, A; Colakoglu, S; Aslan, H; Tunc, AT; Ozen, OA; Turgut, M; Baş, O. (2007). Effects of postnatal formaldehyde exposure on pyramidal cell number, volume of cell layer in hippocampus and hemisphere in the rat: A stereological study. Brain Res 11: 157–167. 10.1016/j.brainres.2007.01.139.
Sarsilmaz, M; Ozen, OA; Akpolat, N; Kus, I; Songur, A. (1999). The histopathologic effects of inhaled formaldehyde on leydig cells of the rats in subacute period. Firat Univ Med Sci J 13: 37–40.
Sarto, F; Finotto, S; Giacomelli, L; Mazzotti, D; Tomanin, R; Levis, AG. (1987). The micronucleus assay in exfoliated cells of the human buccal mucosa. Mutagenesis 2: 11–17. 10.1093/mutage/2.1.11.3331688
Sauder, LR; Chatham, MD; Green, DJ; Kulle, TJ. (1986). Acute pulmonary response to formaldehyde exposure in healthy nonsmokers. J Occup Environ Med 28: 420–424. 10.1097/00043764-198606000-00008.
Sauder, LR; Green, DJ; Chatham, MD; Kulle, TJ. (1987). Acute pulmonary response of asthmatics to 3.0 ppm formaldehyde. Toxicol Ind Health 3: 569–578. 10.1177/074823378700300408.3433289
Saurel-Cubizolles, MJ; Hays, M; Estryn-Behar, M. (1994). Work in operating rooms and pregnancy outcome among nurses. Int Arch Occup Environ Health 66: 235–241. 10.1007/bf00454361.7843833
Saurel-Cubizolles, MJ; Job-Spira, N; Estryn-Behar, M. (1993). Ectopic pregnancy and occupational exposure to antineoplastic drugs. Lancet 341: 1169–1171. 10.1016/0140-6736(93)91000-C.8098075
Savage, JR. (1976). Classification and relationships of induced chromosomal structural changes. J Med Genet 13: 103–122. 10.1136/jmg.13.2.103.933108
Sax, SN; Bennett, DH; Chillrud, SN; Kinney, PL; Spengler, JD. (2004). Differences in source emission rates of volatile organic compounds in inner-city residences of New York City and Los Angeles. J Expo Anal Environ Epidemiol 14: S95–S109. 10.1038/sj.jea.7500364.15118751
Schachter, EN; Witek T J, J. R.; Tosun, T; Leaderer, BP; Beck, GJ. (1986a). A STUDY OF RESPIRATORY EFFECTS FROM EXPOSURE TO 2 PARTS-PER-MILLION FORMALDEHYDE IN HEALTHY SUBJECTS. Arch Environ Health 41: 229–239.3767432
Schachter, EN; Witek, TJ, Jr; Brody, DJ; Tosun, T; Beck, GJ; Leaderer, BP. (1987). A study of respiratory effects from exposure to 2.0 ppm formaldehyde in occupationally exposed workers. Environ Res 44: 188–205. 10.1016/S0013-9351(87)80227-X.3691441
Schachter, EN; Witek, TJ, Jr; Tosun, T; Leaderer, BP; Beck, GJ. (1986b). A study of respiratory effects from exposure to 2 ppm formaldehyde in healthy subjects. Arch Environ Occup Health 41: 229–239. 10.1080/00039896.1986.9938338.
Schafer, D; Brommer, C; Riechelmann, H; Mann, JW. (1999). In vivo and in vitro effect of ozone and formaldehyde on human nasal mucociliary transport system. Rhinology 37: 56–60.10416249
Schenker, MB; Weiss, ST; Murawski, BJ. (1982). Health effects of residence in homes with urea formaldehyde foam insulation: A pilot study. Environ Int 8: 359–363. 10.1016/0160-4120(82)90050-2.
Schlink, K; Janssen, K; Nitzsche, S; Gebhard, S; Hengstler, JG; Klein, S; Oesch, F. (1999). Activity of O6-methylguanine DNA methyltransferase in mononuclear blood cells of formaldehyde-exposed medical students. Arch Toxicol 73: 15–21. 10.1007/s002040050581.10207610
Schlosser, PM. (1999). Relative roles of convection and chemical reaction for the disposition of formaldehyde and ozone in nasal mucus. Inhal Toxicol 11: 967–980. 10.1080/089583799196736.10509029
Schlosser, PM; Lilly, PD; Conolly, RB; Janszen, DB; Kimbell, JS. (2003). Benchmark dose risk assessment for formaldehyde using airflow modeling and a single-compartment, DNA-protein cross-link dosimetry model to estimate human equivalent doses. Risk Anal 23: 473–487. 10.1111/1539-6924.00328.12836840
Schmid, E; Göggelmann, W; Bauchinger, M. (1986). Formaldehyde-induced cytotoxic, genotoxic and mutagenic response in human lymphocytes and Salmonella typhimurium. Mutagenesis 1: 427–431. 10.1093/mutage/1.6.427.3331682
Schmid, O; Speit, G. (2007). Genotoxic effects induced by formaldehyde in human blood and implications for the interpretation of biomonitoring studies. Mutagenesis 22: 69–74. 10.1093/mutage/gel053.17158519
Schoenberg, JB; Mitchell, CA. (1975). Airway disease caused by phenolic (phenol-formaldehyde) resin exposure. Arch Environ Health 30: 574–577. 10.1080/00039896.1975.10666782.128330
Schreiber, H; Bibbo, M; Wied, GL; Saccomanno, G; Nettesheim, P. (1979). Bronchial metaplasia as a benign or premalignant lesion. I. Cytologic and ultrastructural discrimination between acute carcinogen effects and toxin-induced changes. Acta Cytol 23: 496–503.295169
Schreider, JP. (1986). Comparative anatomy and function of the nasal passages. In CS Barrow (Ed.), Toxicology of the nasal passages (pp. 1–25). Washington, DC: Hemisphere Publishing Corporation.
Schroeter, JD; Campbell, J; Kimbell, JS; Conolly, RB; Clewell, HJ; Andersen, ME. (2014). Effects of endogenous formaldehyde in nasal tissues on inhaled formaldehyde dosimetry predictions in the rat, monkey, and human nasal passages. Toxicol Sci 138: 412–424. 10.1093/toxsci/kft333.24385418
Schuck, EA; Stephens, ER; Middleton, JT. (1966). Eye irritation response at low concentrations of irritants. Arch Environ Health 13: 570–575.5925628
Schuiling, M; Zuidhof, AB; Zaagsma, J; Meurs, H. (1999). Involvement of tachykinin NK1 receptor in the development of allergen-induced airway hyperreactivity and airway inflammation in conscious, unrestrained guinea pigs. Am J Respir Crit Care Med 159: 423–430. 10.1164/ajrccm.159.2.9804125.9927353
Schulte-Hermann, R; Bursch, W; Grasl-Kraupp, B; Marian, B; Török, L; Kahl-Rainer, P; Ellinger, A. (1997). Concepts of cell death and application to carcinogenesis. Toxicol Pathol 25: 89–93. 10.1177/019262339702500117.9061858
Schulte-Hermann, R; Bursch, W; Marian, B; Grasl-Kraupp, B. (1999). Active cell death (apoptosis) and cellular proliferation as indicators of exposure to carcinogens. In D McGregor; JM Rice; S Venitt (Eds.), The use of short- and medium-term tests for carcinogens and data on genetic effects in carcinogenic hazard evaluation (pp. 273–285). Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Scientific-Publications/The-Use-Of-Short--And-Medium-term-Tests-For-Carcinogens-And-Data-On-Genetic-Effects-In-Carcinogenic-Hazard-Evaluation-1999.
Schwarze, J; Cieslewicz, G; Hamelmann, E; Joetham, A; Shultz, LD; Lamers, MC; Gelfand, EW. (1999). IL-5 and eosinophils are essential for the development of airway hyperresponsiveness following acute respiratory syncytial virus infection. J Immunol 162: 2997–3004.10072551
SCOEL (Scientific Committee on Occupational Exposure Limits). (2017). SCOEL/REC/125 formaldehyde: recommendation from the scientific committee on occupational exposure limits.
Seals, RM; Kioumourtzoglou, MA; Gredal, O; Hansen, J; Weisskopf, MG. (2017). Occupational formaldehyde and amyotrophic lateral sclerosis. Eur J Epidemiol 32: 893–899. 10.1007/s10654-017-0249-8.28585120
Seitz, T; Baron, S. (1990). Health Hazard Evaluation Report HETA87-349-2022, Rockcastle Manufacturing, Mount Vernon, Kentucky (pp. 38). (NTIS/02970481_a). Seitz, T; Baron, S.
Sellakumar, AR; Snyder, CA; Solomon, JJ; Albert, RE. (1985). Carcinogenicity of formaldehyde and hydrogen chloride in rats. Toxicol Appl Pharmacol 81: 401–406. 10.1016/0041-008X(85)90411-9.4082190
Senichenkova, II. (1991a). Embryotoxic effects of industrial environment pollutants: Formaldehyde and gasoline. Gig Sanit -: 35–38.
Senichenkova, II. (1991b). [Embryotoxic effects of industrial environment pollutants: formaldehyde and gasoline]. Gig Sanit -: 35–38.
Senichenkova, IN; Chebotar, NA. (1996a). [The effect of benzine and formaldehyde on the prenatal development of rats with induced iron trace-element disorder]. Ontogenez 27: 108–113.8725437
Senichenkova, IN; Chebotar, NA. (1996b). Effects of gasoline and formaldehyde on prenatal development of rats with induced iron micronutrient disorder (iron deficiency). Ontogenez 27: 108–113.8725437
Seow, WJ; Zhang, L; Vermeulen, R; Tang, X; Hu, W; Bassig, BA; Ji, Z; Shiels, MS; Kemp, TJ; Shen, M; Qiu, C; Reiss, B; Beane Freeman, LE; Blair, A; Kim, C; Guo, W; Wen, C; Li, L; Pinto, LA; Huang, H; Smith, MT; Hildesheim, A; Rothman, N; Lan, Q. (2015). Circulating immune/inflammation markers in Chinese workers occupationally exposed to formaldehyde. Carcinogenesis 36: 852–857. 10.1093/carcin/bgv055.25908645
Sernia, S; Di Folco, F; Altrudo, P; Sbriccoli, B; Sestili, C; Colamesta, V; Del Buono, S; Michetti, A; Ortis, M; Dawodu, A; Villari, P; La Torre, G. (2016). [Risk of nasopharyngeal cancer, Leukemia and other tumors in a cohort of employees and students potentially exposed to (FA) formaldehyde in University laboratories]. Clin Ter 167: 43–47. 10.7417/CT.2016.1925.27212573
Serre, K; Mohr, E; Gaspal, F; Lane, PJ; Bird, R; Cunningham, AF; Maclennan, IC. (2010). IL-4 directs both CD4 and CD8 T cells to produce Th2 cytokines in vitro, but only CD4 T cells produce these cytokines in response to alum-precipitated protein in vivo. Mol Immunol 47: 1914–1922. 10.1016/j.molimm.2010.03.010.20392496
Sexton, K; Liu, KS; Petreas, MX. (1986). Formaldehyde concentrations inside private residences: A mail-out approach to indoor air monitoring. J Air Pollut Control Assoc 36: 698–704. 10.1080/00022470.1986.10466104.3734250
Sexton, K; Petreas, MX; Liu, KS. (1989). Formaldehyde exposures inside mobile homes. Environ Sci Technol 23: 985–988. 10.1021/es00066a009.
Shah, JJ; Singh, HB. (1988). Distribution of volatile organic chemicals in outdoor and indoor air: a national VOCs data base. Environ Sci Technol 22: 1381–1388. 10.1021/es00177a001.22200458
Shaham, J; Bomstein, Y; Gurvich, R; Rashkovsky, M; Kaufman, Z. (2003). DNA-protein crosslinks and p53 protein expression in relation to occupational exposure to formaldehyde. Occup Environ Med 60: 403–409. 10.1136/oem.60.6.403.12771391
Shaham, J; Bomstein, Y; Meltzer, A; Kaufman, Z; Palma, E; Ribak, J. (1996). DNA-protein crosslinks, a biomarker of exposure to formaldehyde - in vitro and in vivo studies. Carcinogenesis 17: 121–126. 10.1093/carcin/17.1.121.8565120
Shaham, J; Bomstein, Y; Melzer, A; Ribak, J. (1997). DNA-protein crosslinks and sister chromatid exchanges as biomarkers of exposure to formaldehyde. Int J Occup Environ Health 3: 95–104. 10.1179/107735297800407695.9891106
Shaham, J; Gurvich, R; Kaufman, Z. (2002). Sister chromatid exchange in pathology staff occupationally exposed to formaldehyde. Mutat Res Genet Toxicol Environ Mutagen 514: 115–123. 10.1016/S1383-5718(01)00334-5.
Shangina, O; Brennan, P; Szeszenia-Dabrowska, N; Mates, D; Fabiánová, E; Fletcher, T; T’Mannetje, A; Boffetta, P; Zaridze, D. (2006). Occupational exposure and laryngeal and hypopharyngeal cancer risk in central and eastern Europe. Am J Epidemiol 164: 367–375. 10.1093/aje/kwj208.16801374
She, Y; Li, Y; Liu, Y; Asai, G; Sun, S; He, J; Pan, Z; Cui, Y. (2013). Formaldehyde induces toxic effects and regulates the expression of damage response genes in BM-MSCs. Acta Biochim Biophys Sin 45: 1011–1020. 10.1093/abbs/gmt105.24077345
Sheppard, D; Eschenbacher, W; Epstein, J. (1984). Lack of bronchomotor response to up to 3 ppm formaldehyde in subjects with asthma. Environ Res 35: 133–139. 10.1016/0013-9351(84)90120-8.6489284
Sheveleva, G. (1971). Study of the specific effect of formaldehyde on the embryogenesis and progeny of white rats. Toksikol Nov Prom Khim Veshchestv 12: 78–86.
Shi, L; Lebrun, P; Camu, F; Zizi, M. (2004). Intrathecal catheterization and solvents interfere with cortical somatosensory evoked potentials used in assessing nociception in awake rats. Anesth Analg 99: 159–165. 10.1213/01.ane.0000114552.20268.7f.15281523
Shibamoto, T. (2006). Analytical methods for trace levels of reactive carbonyl compounds formed in lipid peroxidation systems [Review]. J Pharm Biomed Anal 41: 12–25. 10.1016/j.jpba.2006.01.047.16497470
Shin, YS; Takeda, K; Gelfand, EW. (2009). Understanding asthma using animal models. Allergy Asthma Immunol Res 1: 10–18. 10.4168/aair.2009.1.1.10.20224665
Sholapuri, P; Chintha, V; Matcha, B; Pradeepkiran, J. (2020). Beneficial effects of polyherbal formulation (Bronco-T) on formaldehyde-induced lung toxicity in male Wistar rats. Toxicology Research 9: 798–807. 10.1093/toxres/tfaa083.33447364
Shumilina, AV. (1975). [Menstrual and child-bearing functions of female workers occupationally exposed to the effects of formaldehyde]. Gig Tr Prof Zabol 18–21.
Shusterman, D. (2007). Trigeminally-mediated health effects of air pollutants: Sources of inter-individual variability [Review]. Hum Exp Toxicol 26: 149–157. 10.1177/0960327107070550.17439917
Siboulet, R; Grinfeld, S; Deparis, P; Jaylet, A. (1984). Micronuclei in red blood cells of the newt Pleurodeles waltl Michah: induction with X-rays and chemicals. Mutat Res 125: 275–281. 10.1016/0027-5107(84)90077-0.6700609
Siemiatycki, J; Wacholder, S; Richardson, L; Dewar, R; Gérin, M. (1987). Discovering carcinogens in the occupational environment: Methods of data collection and analysis of a large case-referent monitoring system. Scand J Work Environ Health 13: 486–492.3433050
Siew, C; Deitrich, RA; Erwin, VG. (1976). Localization and characteristics of rat liver mitochondrial aldehyde dehydrogenases. Arch Biochem Biophys 176: 638–649. 10.1016/0003-9861(76)90208-3.10852
Siew, SS; Kauppinen, T; Kyyrönen, P; Heikkilä, P; Pukkala, E. (2012). Occupational exposure to wood dust and formaldehyde and risk of nasal, nasopharyngeal, and lung cancer among Finnish men. Cancer Management and Research 4: 223–232. 10.2147/CMAR.S30684.22904644
Silva Ibrahim, B; Miranda da Silva, C; Barioni, ÉD; Correa-Costa, M; Drewes, CC; Saraiva Câmara, NO; Tavares-De-Lima, W; Poliselli Farsky, SH; Lino-Dos-Santos-Franco, A. (2015). Formaldehyde inhalation during pregnancy abolishes the development of acute innate inflammation in offspring. Toxicol Lett 235: 147–154. 10.1016/j.toxlet.2015.04.001.25845602
Singh, NP; Mccoy, MT; Tice, RR; Schneider, EL. (1988). A simple technique for quantitation of low levels of DNA damage in individual cells. Exp Cell Res 175: 184–191. 10.1016/0014-4827(88)90265-0.3345800
Skrzydlewska, E. (2003). Toxicological and metabolic consequences of methanol poisoning. Toxicol Mech Meth 13: 277–293. 10.1080/713857189.
Slater, TF. (1984). Free-radical mechanisms in tissue injury [Review]. Biochem J 222: 1–15.6383353
Slikker, W, Jr; Andersen, ME; Bogdanffy, MS; Bus, JS; Cohen, SD; Conolly, RB; David, RM; Doerrer, NG; Dorman, DC; Gaylor, DW; Hattis, D; Rogers, JM; Setzer, RW; Swenberg, JA; Wallace, K. (2004). Dose-dependent transitions in mechanisms of toxicity: Case studies [Review]. Toxicol Appl Pharmacol 201: 226–294. 10.1016/j.taap.2004.06.027.15582646
Smedje, G; Norback, D. (2001). Incidence of asthma diagnosis and self-reported allergy in relation to the school environment: A four-year follow-up study in schoolchildren. Int J Tuberc Lung Dis 5: 1059–1066.11716342
Smedje, G; Norbäck, D; Edling, C. (1997). Asthma among secondary schoolchildren in relation to the school environment. Clin Exp Allergy 27: 1270–1278. 10.1046/j.1365-2222.1997.1780977.x.9420130
Smith, AE; Coit, DW. (1995). Penalty functions. In T Back; DB Fogel; Z Michalewicz (Eds.), Environmental computation 2 (pp. 41–48). New York, NY: Institute of Physics Publishing and Oxford University Press. http://citeseerx.ist.psu.edu/viewdoc/download?doi=10.1.1.39.4841&rep=rep1&type=pdf.
Snedecor, GW; Cochran, WG. (1980). Statistical methods (7th ed.). Ames, IA: Iowa State University Press.
Snyder, RD; van Houten, B. (1986). Genotoxicity of formaldehyde and an evaluation of its effects on the DNA repair process in human diploid fibroblasts. Mutat Res DNA Repair 165: 21–30. 10.1016/0167-8817(86)90005-2.2417114
Sobels, FH; van Steenis, H. (1957). Chemical induction of crossing-over in Drosophila males. Nature 179: 29–31. 10.1038/179029a0.13387745
Soffritti, M; Tibaldi, E, va; Padovani, M; Hoel, DG; Giuliani, L; Bua, L; Lauriola, M; Falcioni, L; Manservigi, M; Manservisi, F; Belpoggi, F. (2016). Synergism between sinusoidal-50Hz magnetic field and formaldehyde in triggering carcinogenic effects in male Sprague-Dawley rats. Am J Ind Med 59: 509–521. 10.1002/ajim.22598.27219869
Solet, D; Zoloth, SR; Sullivan, C; Jewett, J; Michaels, DM. (1989). Patterns of mortality in pulp and paper workers. J Occup Med 31: 627–630.2769460
Song, J; Kang, J; Lin, B; Li, J; Zhu, Y; Du, J; Yang, X; Xi, Z; Li, R. (2017). Mediating role of TRPV1 ion channels in the co-exposure to PM2.5 and formaldehyde of balb/c mice asthma model. Sci Rep 7: 11926. 10.1038/s41598-017-11833-6.28931832
Songur, A; Akpolat, N; Kus, I; Ozen, OA; Zararsiz, I; Sarsilmaz, M. (2003). The effects of the inhaled formaldehyde during the early postnatal period in the hippocampus of rats: A morphological and immunohistochemical study. Neurosci Res Commun 33: 168–178. 10.1002/nrc.10093.
Songur, A; Ozen, OA; Sarsilmaz, M. (2010). The toxic effects of formaldehyde on the nervous system [Review]. Rev Environ Contam Toxicol 203: 105–118. 10.1007/978-1-4419-1352-4_3.19957118
Songur, A; Sarsilmaz, M; Özen, OA. (2008). The effects of inhaled formaldehyde on oxidant and antioxidant systems of rat cerebellum during the postnatal development process. Toxicol Mech Meth 18: 569–574. 10.1080/15376510701555288.
Sorg, BA; Bailie, TM; Tschirgi, ML; Li, N; Wu, WR. (2001a). Exposure to repeated low-level formaldehyde in rats increases basal corticosterone levels and enhances the corticosterone response to subsequent formaldehyde. Brain Res 898: 314–320. 10.1016/S0006-8993(01)02208-9.11306018
Sorg, BA; Davidson, DL; Hochstatter, T; Sylvester, PW. (2002). Repeated cocaine decreases the avoidance response to a novel aversive stimulus in rats. Psychopharmacology 163: 9–19. 10.1007/s00213-002-1133-z.12185395
Sorg, BA; Hochstatter, T. (1999). Behavioral sensitization after repeated formaldehyde exposure in rats. Toxicol Ind Health 15: 346–355. 10.1177/074823379901500309.10416287
Sorg, BA; Swindell, S; Tschirgi, ML. (2004). Repeated low level formaldehyde exposure produces enhanced fear conditioning to odor in male, but not female, rats. Brain Res 1008: 11–19. 10.1016/j.brainres.2004.02.015.15081377
Sorg, BA; Tschirgi, ML; Swindell, S; Chen, L; Fang, J. (2001b). Repeated formaldehyde effects in an animal model for multiple chemical sensitivity [Review]. Ann N Y Acad Sci 933: 57–67. 10.1111/j.1749-6632.2001.tb05814.x.12000036
Sorg, BA; Willis, JR; Nowatka, TC; Ulibarri, C; See, RE; Westberg, HH. (1996). Proposed animal neurosensitization model for multiple chemical sensitivity in studies with formalin. Toxicology 111: 135–145. 10.1016/0300-483x(96)03371-9.8711729
Sorg, BA; Willis, JR; See, RE; Hopkins, B; Westberg, HH. (1998). Repeated low-level formaldehyde exposure produces cross-sensitization to cocaine: Possible relevance to chemical sensitivity in humans. Neuropsychopharmacology 18: 385–394. 10.1038/sj.npp.1395160.9536452
Sorokin, SP. (1988). The respiratory system. In L Weiss (Ed.), Cell and tissue biology: A textbook of histology (6th ed., pp. 751–814). Baltimore, MD: Urban & Schwarzenberg.
Souza, AD; Devi, R. (2014). Cytokinesis blocked micronucleus assay of peripheral lymphocytes revealing the genotoxic effect of formaldehyde exposure. Clin Anat 27: 308–312. 10.1002/ca.22291.23893659
Speit, G; Kühner, S; Linsenmeyer, R; Schütz, P. (2011a). Does formaldehyde induce aneuploidy. Mutagenesis 26: 805–811. 10.1093/mutage/ger050.21804075
Speit, G; Ladeira, C; Linsenmeyer, R; Schütz, P; Högel, J. (2012). Re-evaluation of a reported increased micronucleus frequency in lymphocytes of workers occupationally exposed to formaldehyde. Mutat Res 744: 161–166. 10.1016/j.mrgentox.2012.02.009.22405975
Speit, G; Merk, O. (2002). Evaluation of mutagenic effects of formaldehyde in vitro: Detection of crosslinks and mutations in mouse lymphoma cells. Mutagenesis 17: 183–187. 10.1093/mutage/17.3.183.11971987
Speit, G; Neuss, S; Schuetz, P; Froehler-Keller, M; Schmid, O. (2008a). The genotoxic potential of glutaraldehyde in mammalian cells in vitro in comparison with formaldehyde. Mutat Res Genet Toxicol Environ Mutagen 649: 146–154. 10.1016/j.mrgentox.2007.08.010.
Speit, G; Schmid, O; Fröhler-Keller, M; Lang, I; G, T. (2007a). Assessment of local genotoxic effects of formaldehyde in humans measured by the micronucleus test with exfoliated buccal mucosa cells. Mutat Res Genet Toxicol Environ Mutagen 627: 129–135. 10.1016/j.mrgentox.2006.10.013.
Speit, G; Schmid, O; Neuss, S; Schütz, P. (2008b). Genotoxic effects of formaldehyde in the human lung cell line A549 and in primary human nasal epithelial cells. Environ Mol Mutagen 49: 300–307. 10.1002/em.20386.18366098
Speit, G; Schutz, P; Hogel, J; Schmid, O. (2007b). Characterization of the genotoxic potential of formaldehyde in V79 cells. Mutagenesis 22: 387–394. 10.1093/mutage/gem031.17855734
Speit, G; Schutz, P; Merk, O. (2000). Induction and repair of formaldehyde-induced DNA-protein crosslinks in repair-deficient human cell lines. Mutagenesis 15: 85–90. 10.1093/mutage/15.1.85.10640535
Speit, G; Schütz, P; Weber, I; Ma-Hock, L; Kaufmann, W; Gelbke, HP; Durrer, S. (2011b). Analysis of micronuclei, histopathological changes and cell proliferation in nasal epithelium cells of rats after exposure to formaldehyde by inhalation. Mutat Res 721: 127–135. 10.1016/j.mrgentox.2011.01.008.21272661
Speit, G; Zeller, J; Schmid, O; Elhajouji, A; Ma-Hock, L; Neuss, S. (2009). Inhalation of formaldehyde does not induce systemic genotoxic effects in rats. Mutat Res Genet Toxicol Environ Mutagen 677: 76–85. 10.1016/j.mrgentox.2009.05.020.
Srám, RJ. (1970). The effect of storage on the frequency of dominant lethals in Drosophila melanogaster. MGG Mol gen genet 106: 286–288.5480469
Sripaiboonkij, P; Sripaiboonkij, N; Phanprasit, W; Jaakkola, MS. (2009). Respiratory and skin health among glass microfiber production workers: a cross-sectional study. Environ Health 8: 36. 10.1186/1476-069X-8-36.19689806
Starr, TB; Swenberg, JA. (2013). A novel bottom-up approach to bounding low-dose human cancer risks from chemical exposures. Regul Toxicol Pharmacol 65: 311–315. 10.1016/j.yrtph.2013.01.004.23352840
Starr, TB; Swenberg, JA. (2016). The bottom-up approach to bounding potential low-dose cancer risks from formaldehyde: An update. Regul Toxicol Pharmacol 77: 167–174. 10.1016/j.yrtph.2016.01.021.26851508
Stayner, LT; Elliott, L; Blade, L; Keenlyside, R; Halperin, W. (1988). A retrospective cohort mortality study of workers exposed to formaldehyde in the garment industry. Am J Ind Med 13: 667–681. 10.1002/ajim.4700130606.3389362
Steele, LL; Wilkins, J. R. (1996). Occupational exposures and risks of spontaneous abortion among female veterinarians. Int J Occup Environ Health 2: 26–36.9933862
Stellman, SD; Demers, PA; Colin, D; Boffetta, P. (1998). Cancer mortality and wood dust exposure among participants in the American Cancer Society Cancer Prevention Study-II (CPS-II). Am J Ind Med 34: 229–237. 10.1002/(SICI)1097-0274(199809)34:3<229::AID-AJIM4>3.0.CO;2-Q.9698991
Stern, FB. (2003). Mortality among chrome leather tannery workers: an update. Am J Ind Med 44: 197–206. 10.1002/ajim.10242.12874853
Stewart, PA; Blair, A; Cubit, DA; Bales, RE; Kaplan, SA; Ward, J; Gaffey, W; O’Berg, MT; Walrath, J. (1986). Estimating historical exposures to formaldehyde in a retrospective mortality study. Appl Ind Hyg 1: 34–41.
Stich, HF; Curtis, JR; Parida, BB. (1982). Application of the micronucleus test to exfoliated cells of high cancer risk groups: Tobacco chewers. Int J Cancer 30: 553–559. 10.1002/ijc.2910300504.6759419
Strait, RT; Morris, SC; Finkelman, FD. (2006). IgG-blocking antibodies inhibit IgE-mediated anaphylaxis in vivo through both antigen interception and Fc gamma RIIb cross-linking. J Clin Invest 116: 833–841. 10.1172/JCI25575.16498503
Stroup, NE; Blair, A; Erikson, GE. (1986). Brain cancer and other causes of death in anatomists. J Natl Cancer Inst 77: 1217–1224.3467114
Stücker, I; Caillard, JF; Collin, R; Gout, M; Poyen, D; Hémon, D. (1990). Risk of spontaneous abortion among nurses handling antineoplastic drugs. Scand J Work Environ Health 16: 102–107. 10.5271/sjweh.1811.2353192
Stücker, I; Mandereau, L; Hémon, D. (1993). Relationship between birthweight and occupational exposure to cytostatic drugs during or before pregnancy. Scand J Work Environ Health 19: 148–153. 10.5271/sjweh.1488.8367691
Stumm-Tegethoff, BFA. (1969). Formaldehyde-induced mutations in Drosophila melanogaster in dependence of the presence of acids. Theor Appl Genet 39: 330–334. 10.1007/BF00281915.24435561
Subramaniam, RP; Chen, C; Crump, KS; Devoney, D; Fox, JF; Portier, CJ; Schlosser, PM; Thompson, CM; White, P. (2008). Uncertainties in biologically-based modeling of formaldehyde-induced respiratory cancer risk: Identification of key issues. Risk Anal 28: 907–923. 10.1111/j.1539-6924.2008.01083.x.18564991
Subramaniam, RP; Crump, KS; Van Landingham, C; White, P; Chen, C; Schlosser, PM. (2007). Uncertainties in the CIIT model for formaldehyde-induced carcinogenicity in the rat: A limited sensitivity analysis–I. Risk Anal 27: 1237–1254. 10.1111/j.1539-6924.2007.00968.x.18076493
Subramaniam, RP; Richardson, RB; Morgan, KT; Kimbell, JS; Guilmette, RA. (1998). Computational fluid dynamics simulations of inspiratory airflow in the human nose and nasopharynx. Inhal Toxicol 10: 91–120. 10.1080/089583798197772.
Sul, D; Kim, H; Oh, E; Phark, S; Cho, E; Choi, S; Kang, HS; Kim, EM; Hwang, KW; Jung, WW. (2007). Gene expression profiling in lung tissues from rats exposed to formaldehyde. Arch Toxicol 81: 589–597. 10.1007/s00204-007-0182-9.17285311
Suruda, A; Schulte, P; Boeniger, M; Hayes, RB; Livingston, GK; Steenland, K; Stewart, P; Herrick, R; Douthit, D; Fingerhut, MA. (1993). Cytogenetic effects of formaldehyde exposure in students of mortuary science. Cancer Epidemiol Biomarkers Prev 2: 453–460.8220090
Suskov, II; Sazonova, LA. (1982). Cytogenetic effects of epoxy, phenolformaldehyde and polyvinylchloride resins in man. Mutat Res 104: 137–140. 10.1016/0165-7992(82)90134-8.7078566
Sutton, HC; Downes, TM. (1972). Rate of hydration of formaldehyde in aqueous solution. J Chem Soc Chem Commun 1. 10.1039/C39720000001.
Suzuki, H; Miura, S; Liu, YY; Tsuchiya, M; Ishii, H. (1995). Substance P induces degranulation of mast cells and leukocyte adhesion to venular endothelium. Peptides 16: 1447–1452. 10.1016/0196-9781(95)02050-0.8745057
Svensson, S; Some, M; Lundsjö, A; Helander, A; Cronholm, T; Höög, JO. (1999). Activities of human alcohol dehydrogenases in the metabolic pathways of ethanol and serotonin. Eur J Biochem 262: 324–329. 10.1046/j.1432-1327.1999.00351.x.10336614
Swenberg, J; Kerns, W; Pavkov, K; Mitchell, R; Gralla, EJ. (1980a). Carcinogenicity of formaldehyde vapor: interim findings in a long-term bioassay of rats and mice. Dev Toxicol Environ Sci 8: 283–286.7308029
Swenberg, JA; Gross, EA; Martin, J; Popp, JA. (1983a). Mechanisms of formaldehyde toxicity. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 132–147). Washington, DC: Hemisphere Publishing.
Swenberg, JA; Gross, EA; Randall, HW. (1986). Localization and quantitation of cell proliferation following exposure to nasal irritants. In CS Barrow (Ed.), Toxicology of the nasal passages (pp. 291–300). New York, NY: Hemisphere Publishing Corp.
Swenberg, JA; Gross, EA; Randall, HW; Barrow, CS. (1983b). The effect of formaldehyde exposure on cytotoxicity and cell proliferation. In JJ Clary; JE Gibson; RS Waritz (Eds.), Formaldehyde, toxicology, epidemiology, mechanisms (pp. 225–236). New York, NY: Marcel Dekker.
Swenberg, JA; Kerns, WD; Mitchell, RI; Gralla, EJ; Pavkov, KL. (1980b). Induction of squamous cell carcinomas of the rat nasal cavity by inhalation exposure to formaldehyde vapor. Cancer Res 40: 3398–3402.7427950
Swenberg, JA; Lu, K; Moeller, BC; Gao, L; Upton, PB; Nakamura, J; Starr, TB. (2011). Endogenous versus exogenous DNA adducts: Their role in carcinogenesis, epidemiology, and risk assessment [Review]. Toxicol Sci 120: S130–S145. 10.1093/toxsci/kfq371.21163908
Swiecichowski, AL; Long, KJ; Miller, ML; Leikauf, GD. (1993). Formaldehyde-induced airway hyperreactivity in vivo and ex vivo in guinea pigs. Environ Res 61: 185–199. 10.1006/enrs.1993.1063.8495661
Taffet, GE; Donohue, JF; Altman, PR. (2014). Considerations for managing chronic obstructive pulmonary disease in the elderly [Review]. Clinical Interventions in Aging 9: 23–30. 10.2147/CIA.S52999.24376347
Takahashi, K; Morita, T; Kawazoe, Y. (1985). Mutagenic characteristics of formaldehyde on bacterial systems. Mutat Res 156: 153–161. 10.1016/0165-1218(85)90058-8.3889633
Takahashi, S; Tsuji, K; Fujii, K; Okazaki, F; Takigawa, T; Ohtsuka, A; Iwatsuki, K. (2007). Prospective study of clinical symptoms and skin test reactions in medical students exposed to formaldehyde gas. J Dermatol 34: 283–289. 10.1111/j.1346-8138.2007.00274.x.17408435
Takigawa, T; Usami, M; Yamasaki, Y; Wang, B; Sakano, N; Horike, T; Kataoka, H; Ohtsuka, A; Kira, S. (2005). Reduction of indoor formaldehyde concentrations and subjective symptoms in a gross anatomy laboratory. Bull Environ Contam Toxicol 74: 1027–1033. 10.1007/s00128-005-0683-2.16158836
Talibov, M; Lehtinen-Jacks, S; Martinsen, JI; Kjærheim, K; Lynge, E; Sparén, P; Tryggvadottir, L; Weiderpass, E; Kauppinen, T; Kyyrönen, P; Pukkala, E. (2014). Occupational exposure to solvents and acute myeloid leukemia: A population-based, case-control study in four Nordic countries. Scand J Work Environ Health 40: 511–517. 10.5271/sjweh.3436.24840289
Tang, LX; Zhang, YS. (2003). [Health investigation on workers exposed to formaldehyde] (pp. 34–35). Tang, LX; Zhang, YS.
Tani, T; Kogi, K; Horiguchi, Y. (1986). Inhibitory effects of formaldehyde inhalation on the cardiovascular and respiratory systems in unanesthetized rabbits. Jpn J Pharmacol 40: 551–559. 10.1254/jjp.40.551.3735804
Tanveer, H; Rastogi, SK; Mathur, N; Gupta, BN. (1995). Respiratory responses of paper mill workers occupationally exposed to formaldehyde. Indian J Indust Med 41: 2–8.
Tarkowski, M; Gorski, P. (1995). Increased IgE antiovalbumin level in mice exposed to formaldehyde. Int Arch Allergy Immunol 106: 422–424. 10.1159/000236876.7719158
Taskinen, H; Kyyronen, P; Hemminki, K. (1994). Laboratory work and pregnancy outcome. J Occup Med 36: 311–319. 10.1097/00043764-199403000-00008.8195901
Taskinen, HK; Kyyronen, P; Sallmen, M; Virtanen, SV; Liukkonen, TA; Huida, O; Lindbohm, ML; Anttila, A. (1999). Reduced fertility among female wood workers exposed to formaldehyde. Am J Ind Med 36: 206–212. 10.1002/(sici)1097-0274(199907)36:1<206::aid-ajim29>3.0.co;2-d.10361608
Tavernier, G; Fletcher, G; Gee, I; Watson, A; Blacklock, G; Francis, H; Fletcher, A; Frank, T; Frank, P; Pickering, CA; Niven, R. (2006). IPEADAM study: Indoor endotoxin exposure, family status, and some housing characteristics in English children. J Allergy Clin Immunol 117: 656–662. 10.1016/j.jaci.2005.12.1311.16522467
Taves, MD; Ashwell, JD. (2020). Glucocorticoids in T cell development, differentiation and function [Review]. Nat Rev Immunol. 10.1038/s41577-020-00464-0.
Taylor-Clark, TE; McAlexander, MA; Nassenstein, C; Sheardown, SA; Wilson, S; Thornton, J; Carr, MJ; Undem, BJ. (2008). Relative contributions of TRPA1 and TRPV1 channels in the activation of vagal bronchopulmonary C-fibres by the endogenous autacoid 4-oxononenal. J Physiol 586: 3447–3459. 10.1113/jphysiol.2008.153585.18499726
Teixeira, JP; Gaspar, J; Silva, S; Torres, J; Silva, SN; Azevedo, MC; Neves, P; Laffon, B; Méndez, J; Gonçalves, C; Mayan, O; Farmer, PB; Rueff, J. (2004). Occupational exposure to styrene: modulation of cytogenetic damage and levels of urinary metabolites of styrene by polymorphisms in genes CYP2E1, EPHX1, GSTM1, GSTT1 and GSTP1. Toxicology 195: 231–242. 10.1016/j.tox.2003.10.010.14751678
Temcharoen, P; Thilly, WG. (1983). Toxic and mutagenic effects of formaldehyde in Salmonella typhimurium. Mutat Res 119: 89–93. 10.1016/0165-7992(83)90115-X.6338371
Teng, S; Beard, K; Pourahmad, J; Moridani, M; Easson, E; Poon, R; O’Brien, PJ. (2001). The formaldehyde metabolic detoxification enzyme systems and molecular cytotoxic mechanism in isolated rat hepatocytes. Chem Biol Interact 130–132: 285–296. 10.1016/S0009-2797(00)00272-6.
Tepper, JS; Moser, VC; Costa, DL; Mason, MA; Roache, N; Guo, Z; Dyer, RS. (1995). Toxicological and chemical evaluation of emissions from carpet samples. Am Ind Hyg Assoc J 56: 158–170. 10.1080/15428119591017196.7856517
Teschke, K; Morgan, MS; Checkoway, H; Franklin, G; Spinelli, JJ; van Belle, G; Weiss, NS. (1997). Surveillance of nasal and bladder cancer to locate sources of exposure to occupational carcinogens. Occup Environ Med 54: 443–451. 10.1136/oem.54.6.443.9245952
Thetkathuek, A; Yingratanasuk, T; Ekburanawat, W. (2016). Respiratory Symptoms due to Occupational Exposure to Formaldehyde and MDF Dust in a MDF Furniture Factory in Eastern Thailand. 2016: 3705824. 10.1155/2016/3705824.
Thomas, P; Holland, N; Bolognesi, C; Kirsch-Volders, M; Bonassi, S; Zeiger, E; Knasmueller, S; Fenech, M. (2009). Buccal micronucleus cytome assay. Nat Protoc 4: 825–837. 10.1038/nprot.2009.53.19444240
Thompson, CM; Ceder, R; Grafström, RC. (2010). Formaldehyde dehydrogenase: beyond phase I metabolism. Toxicol Lett 193: 1–3. 10.1016/j.toxlet.2009.11.023.19963048
Thompson, CM; Sonawane, B; Grafstrom, RC. (2009). The ontogeny, distribution, and regulation of alcohol dehydrogenase 3: Implications for pulmonary physiology [Review]. Drug Metab Dispos 37: 1565–1571. 10.1124/dmd.109.027904.19460944
Thomson, EJ; Shackleton, S; Harrington, JM. (1984). Chromosome aberrations and sister-chromatid exchange frequencies in pathology staff occupationally exposed to formaldehyde. Mutat Res 141: 89–93. 10.1016/0165-7992(84)90016-2.6493271
Thrasher, JD; Broughton, A; Madison, R. (1990). Immune activation and autoantibodies in humans with long-term inhalation exposure to formaldehyde. Arch Environ Health 45: 217–223. 10.1080/00039896.1990.9940805.2400243
Thrasher, JD; Wojdani, A; Cheung, G; Heuser, G. (1987). Evidence for formaldehyde antibodies and altered cellular immunity in subjects exposed to formaldehyde in mobile homes. Arch Environ Health 42: 347–350. 10.1080/00039896.1987.9934357.3439811
Thun, MJ; Lakat, M; Altman, R. (1982). Symptom survey of residents of homes insulated with urea-formaldehyde foam. Environ Res 29: 320–334. 10.1016/0013-9351(82)90034-2.6926753
Tibbetts, AS; Appling, DR. (2010). Compartmentalization of Mammalian folate-mediated one-carbon metabolism [Review]. Annu Rev Nutr 30: 57–81. 10.1146/annurev.nutr.012809.104810.20645850
Tice, RR; Agurell, E; Anderson, D; Burlinson, B; Hartmann, A; Kobayashi, H; Miyamae, Y; Rojas, E; Ryu, JC; Sasaki, YF. (2000). Single cell gel/comet assay: guidelines for in vitro and in vivo genetic toxicology testing. Environ Mol Mutagen 35: 206–221. 10.1002/(sici)1098-2280(2000)35:3<206::aid-em8>3.0.co;2-j.10737956
Titenko-Holland, N; Levine, AJ; Smith, MT; Quintana, PJ; Boeniger, M; Hayes, R; Suruda, A; Schulte, P. (1996). Quantification of epithelial cell micronuclei by fluorescence in situ hybridization (FISH) in mortuary science students exposed to formaldehyde. Mutat Res 371: 237–248. 10.1016/S0165-1218(96)90112-3.9008725
Tobe, M; Kaneko, T; Uchida, Y; Kamata, E; Ogawa, Y; Ikeda, Y; Saito, M. (1985a). Studies on the inhalation toxicity of formaldehyde. 43.
Tobe, M; Kaneko, Y; Uchida, Y; al., e. (1985b). Studies of the inhalation toxicity of formaldehyde. National Sanitary and Medical Laboratory Service, Toxicity, Tokyo, Japan; T-85-0236. Tobe, M; Kaneko, Y; Uchida, Y; et al.
Togias, A. (1999). Mechanisms of nose-lung interaction [Review]. Allergy 54: 94–105. 10.1111/j.1398-9995.1999.tb04410.x.10565484
Togias, A. (2004). Systemic effects of local allergic disease [Review]. J Allergy Clin Immunol 113: S8–14. 10.1016/j.jaci.2003.09.051.14694344
Tolbert, PE; Shy, CM; Allen, JW. (1991). Micronuclei and other nuclear anomalies in buccal smears: a field test in snuff users. Am J Epidemiol 134: 840–850. 10.1093/oxfordjournals.aje.a116159.1951279
Tolbert, PE; Shy, CM; Allen, JW. (1992). Micronuclei and other nuclear anomalies in buccal smears: methods development. Mutat Res 271: 69–77.1371831
Tong, ZM; Zhu, SX; Shi, J. (2007). [Effect of formaldehyde on blood component and blood biochemistry of exposed workers]. 20: 409–410.
Torjussen, W; Solberg, LA; Hogetveit, AC. (1979). Histopathological changes of the nasal mucosa in active and retired nickel workers. Br J Cancer 40: 568–580.497107
Tranah, GJ; Holly, EA; Bracci, PM. (2009). Solvent exposure and non-Hodgkin lymphoma: no risk in a population-based study in the San Francisco Bay Area. Cancer Epidemiol Biomarkers Prev 18: 3130–3132. 10.1158/1055-9965.EPI-09-0821.19900943
Trivedi, SG; Lloyd, CM. (2007). Eosinophils in the pathogenesis of allergic airways disease [Review]. Cell Mol Life Sci 64: 1269–1289. 10.1007/s00018-007-6527-y.17364144
Tsubone, H; Kawata, M. (1991). Stimulation to the trigeminal afferent nerve of the nose by formaldehyde, acrolein, and acetaldehyde gases. Inhal Toxicol 3: 211–222. 10.3109/08958379109145285.
Tsukahara, S; Yamamoto, S; Shwe, TTW; Ahmed, S; Kunugita, N; Arashidani, K; Fujimaki, H. (2006). Inhalation of low-level formaldehyde increases the Bcl-2/Bax expression ratio in the hippocampus of immunologically sensitized mice. Neuroimmunomodulation 13: 63–68. 10.1159/000094829.16888403
Tuluc, F; Lai, JP; Kilpatrick, LE; Evans, DL; Douglas, SD. (2009). Neurokinin 1 receptor isoforms and the control of innate immunity [Review]. Trends Immunol 30: 271–276. 10.1016/j.it.2009.03.006.19427266
Turner, C; Parekh, B; Walton, C; Spanel, P; Smith, D; Evans, M. (2008). An exploratory comparative study of volatile compounds in exhaled breath and emitted by skin using selected ion flow tube mass spectrometry. Rapid Commun Mass Spectrom 22: 526–532. 10.1002/rcm.3402.18215004
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (2000). CatReg software documentation [EPA Report]. (EPA/600/R-98/053). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2002). IRIS Assessment of: 1,3 Butadiene (CASRN 106-99-0). Washington, DC: U.S. Environmental Protection Agency, Intergrated Risk Information System. https://cfpub.epa.gov/ncea/iris2/chemicalLanding.cfm?substance_nmbr=139.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2015). Peer review handbook [EPA Report] (4th ed.). (EPA/100/B-15/001). Washington, DC: U.S. Environmental Protection Agency, Science Policy Council. https://www.epa.gov/osa/peer-review-handbook-4th-edition-2015.
U.S. EPA (U.S. Environmental Protection Agency). (2017). Categorical regression (CATREG) user guide, version 3.1.0.7. BMDS. https://www.epa.gov/sites/production/files/2016-03/documents/catreg_user_guide.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2022). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
Uba, G; Pachorek, D; Bernstein, J; Garabrant, DH; Balmes, JR; Wright, WE; Amar, RB. (1989). Prospective study of respiratory effects of formaldehyde among healthy and asthmatic medical students. Am J Ind Med 15: 91–101. 10.1002/ajim.4700150110.2929612
Ulsamer, AG; Gupta, KC; Cohn, MS; Preuss, PW. (1982). Formaldehyde in indoor air: Toxicity and risk. In Proceedings of the 75th Annual Meeting of the Air Pollution Control Association: Volume 2 (pp. 1–16). Pittsburgh, PA: Air Pollution Control Association.
Uotila, L; Koivusalo, M. (1974). Formaldehyde dehydrogenase from human liver: Purification, properties, and evidence for the formation of glutathione thiol esters by the enzyme. J Biol Chem 249: 7653–7663.4373474
Uotila, L; Koivusalo, M. (1987). Multiple forms of formaldehyde dehydrogenase from human red blood cells. Hum Hered 37: 102–106. 10.1159/000153684.3583286
Uotila, L; Koivusalo, M. (1989). Glutathione-dependent oxidoreductases: Formaldehyde dehydrogenase. In D Dolphin; R Poulson; O Avramovic (Eds.), Glutathione: Chemical, biochemical, and medical aspects (pp. 517–551). New York, NY: Wiley-Interscience.
Usanmaz, SE; Akarsu, ES; Vural, N. (2002). Neurotoxic effects of acute and subacute formaldehyde exposures in mice. Environ Toxicol Pharmacol 11: 93–100. 10.1016/S1382-6689(01)00109-0.21782590
Van de Perre, P. (2003). Transfer of antibody via mother’s milk [Review]. Vaccine 21: 3374–3376. 10.1016/s0264-410x(03)00336-0.12850343
van Helden, YGJ; Keijer, J; Heil, SG; Pico, C; Palou, A; Oliver, P; Munnia, A; Briede, JJ; Peluso, M; Franssen-Van Hal, NL; van Schooten, FJ; Godschalk, RWL. (2009). Beta-carotene affects oxidative stress-related DNA damage in lung epithelial cells and in ferret lung. Carcinogenesis 30: 2070–2076. 10.1093/carcin/bgp186.19638427
Vardoulakis, S; Giagloglou, E; Steinle, S; Davis, A; Sleeuwenhoek, A; Galea, KS; Dixon, K; Crawford, JO. (2020). Indoor Exposure to Selected Air Pollutants in the Home Environment: A Systematic Review [Review]. Int J Environ Res Public Health 17: 1–24. 10.3390/ijerph17238972.
Vargová, M; Janota, S; Karelová, J; Barancokova, M; Sulcova, M. (1992). Analysis of the health risk of occupational exposure to formaldehyde using biological markers. Analusis 20: 451–454.
Vasudeva, N; Anand, C. (1996). Cytogenetic evaluation of medical students exposed to formaldehyde vapor in the gross anatomy dissection laboratory. J Am Coll Health 44: 177–179. 10.1080/07448481.1996.9937526.8583043
Vaughan, TL. (1989). Occupation and squamous cell cancers of the pharynx and sinonasal cavity. Am J Ind Med 16: 493–510. 10.1002/ajim.4700160503.2589327
Vaughan, TL; Davis, S. (1991). Wood dust exposure and squamous cell cancers of the upper respiratory tract. Am J Epidemiol 133: 560–564. 10.1093/oxfordjournals.aje.a115927.2006642
Vaughan, TL; Stewart, PA; Teschke, K; Lynch, CF; Swanson, GM; Lyon, JL; Berwick, M. (2000). Occupational exposure to formaldehyde and wood dust and nasopharyngeal carcinoma. Occup Environ Med 57: 376–384. 10.1136/oem.57.6.376.10810126
Vaughan, TL; Strader, C; Davis, S; Daling, JR. (1986a). Formaldehyde and cancers of the pharynx, sinus and nasal cavity: I. Occupational exposures. Int J Cancer 38: 677–683. 10.1002/ijc.2910380510.3770995
Vaughan, TL; Strader, C; Davis, S; Daling, JR. (1986b). Formaldehyde and cancers of the pharynx, sinus and nasal cavity: II. Residential exposures. Int J Cancer 38: 685–688. 10.1002/ijc.2910380511.3770996
Venn, A. (2012). [Email to Glinda Cooper concerning FW: Follow-up question regarding 2003 wheeze study]. Available online at (accessed
Venn, A; Lewis, S; Cooper, M; Hubbard, R; Hill, I; Boddy, R; Bell, M; Britton, J. (2000). Local road traffic activity and the prevalence, severity and persistence of wheeze in school children: combined cross sectional and longitudinal study. Occup Environ Med 57: 152–158. 10.1136/oem.57.3.152.10810096
Venn, AJ; Cooper, M; Antoniak, M; Laughlin, C; Britton, J; Lewis, SA. (2003). Effects of volatile organic compounds, damp, and other environmental exposures in the home on wheezing illness in children. Thorax 58: 955–960. 10.1136/thorax.58.11.955.14586048
Verma, A. (1998). Cytogenetic investigations on patients with oral submucous fibrosis. J Indian Med Assoc 96: 51–52, 57.9715026
Viegas, S; Ladeira, C; Gomes, M; Nunes, C; Brito, M; Prista, J. (2013). Exposure and genotoxicity assessment methodologies - the case of formaldehyde occupational exposure. Current Analytical Chemistry 9: 476–484. 10.2174/1573411011309030017.
Viegas, S; Ladeira, C; Nunes, C; Malta-Vacas, J; Gomes, M; Brito, M; Mendonca, P; Prista, J. (2010). Genotoxic effects in occupational exposure to formaldehyde: A study in anatomy and pathology laboratories and formaldehyde-resins production. J Occup Med Toxicol 5: 25. 10.1186/1745-6673-5-25.20727169
Villeneuve, DL; Crump, D; Garcia-Reyero, N; Hecker, M; Hutchinson, TH; Lalone, CA; Landesmann, B; Lettieri, T; Munn, S; Nepelska, M; Ottinger, MA; Vergauwen, L; Whelan, M. (2014). Adverse outcome pathway (AOP) development I: Strategies and principles. Toxicol Sci 142: 312–320. 10.1093/toxsci/kfu199.25466378
Vitoux, MA; Kessal, K; Baudouin, C; Laprévote, O; Melik Parsadaniantz, S; Achard, S; Brignole-Baudouin, F. (2018). Formaldehyde gas exposure increases inflammation in an in vitro model of dry eye. Toxicol Sci 165: 108–117. 10.1093/toxsci/kfy125.29860525
Vock, EH; Lutz, WK; Ilinskaya, O; Vamvakas, S. (1999). Discrimination between genotoxicity and cytotoxicity for the induction of DNA double-strand breaks in cells treated with aldehydes and diepoxides. Mutat Res 441: 85–93. 10.1016/S1383-5718(99)00038-8.10224325
Von Hippel, PH; Wong, KY. (1971). Dynamic aspects of native DNA structure: Kinetics of the formaldehyde reaction with calf thymus DNA. J Mol Biol 61: 587–613. 10.1016/0022-2836(71)90066-0.5167307
Vosoughi, S; Khavanin, A; Salehnia, M; Asilian Mahabadi, H; Shahverdi, A; Esmaeili, V. (2013). Adverse effects of formaldehyde vapor on mouse sperm parameters and testicular tissue. Int J Fertility Sterility 6: 250–257.
Vosoughi, S; Khavanin, A; Salehnia, M; Mahabadi, HA; Soleimanian, A. (2012). Effects of simultaneous exposure to formaldehyde vapor and noise on mouse testicular tissue and sperm parameters. Health Scope 1: 110–117. 10.17795/jhealthscope-7973.
Walker, JF. (1975). Formaldehyde (3rd ed.). R.E. Krieger Publishing Company: Huntington, NY.
Wallner, P; Kundi, M; Moshammer, H; Piegler, K; Hohenblum, P; Scharf, S; Fröhlich, M; Damberger, B; Tapplere, P; Hutter, HP. (2012). Indoor air in schools and lung function of Austrian school children. J Environ Monit 14: 1976–1982. 10.1039/c2em30059a.22652689
Walrath, J; Fraumeni, JF, Jr. (1983). Mortality patterns among embalmers. Int J Cancer 31: 407–411. 10.1002/ijc.2910310403.6832852
Walrath, J; Fraumeni, JF, Jr. (1984). Cancer and other causes of death among embalmers. Cancer Res 44: 4638–4641.6467219
Walrath, J; Jr, FJ. (1983). Proportionate mortality among New York embalmers. In JE Gibson (Ed.), Formaldehyde toxicity (pp. 227–236). Washington, DC: Hemispheres Publishing Corporation.
Wang, B; Liu, DD. (2006). [Detection of formaldehyde induced developmental toxicity assessed with single cell gel electrophoresis]. Fen Zi Xi Bao Sheng Wu Xue Bao 39: 462–466.17117557
Wang, F, an; Li, C; Liu, W, ei; Jin, Y. (2014a). Potential mechanisms of neurobehavioral disturbances in mice caused by sub-chronic exposure to low-dose VOCs. Inhal Toxicol 26: 250–258. 10.3109/08958378.2014.882447.24568580
Wang, H; Li, H, eC; Lv, M; Zhou, D; Bai, L; Du, L; Xue, X, ia; Lin, P, u; Qiu, S. (2015). Associations between occupation exposure to Formaldehyde and semen quality, a primary study. Sci Rep 5: 15874. 10.1038/srep15874.26515386
Wang, HB; Ghiran, I; Matthaei, K; Weller, PF. (2007a). Airway eosinophils: allergic inflammation recruited professional antigen-presenting cells. J Immunol 179: 7585–7592.18025204
Wang, HX; Wang, XY; Zhou, DX; Zheng, LR; Zhang, J; Huo, YW; Tian, H. (2013). Effects of low-dose, long-term formaldehyde exposure on the structure and functions of the ovary in rats. Toxicol Ind Health 29: 609–615. 10.1177/0748233711430983.22287616
Wang, HX; Zhou, DX; Zheng, LR; Zhang, J; Huo, YW; Tian, H; Han, SP; Zhang, J; Zhao, WB. (2012). Effects of paternal occupation exposure to formaldehyde on reproductive outcomes. J Occup Environ Med 54: 518–524. 10.1097/JOM.0b013e31824e6937.22576458
Wang, K; Wang, TW; Xu, J; Zhu, Y; Jian, L; Au, W; Xia, ZL. (2019). Determination of benchmark dose based on adduct and micronucleus formations in formaldehyde-exposed workers. Int J Hyg Environ Health 222: 738–743. 10.1016/j.ijheh.2019.05.008.31147150
Wang, M; Cheng, G; Balbo, S; Carmella, SG; Villalta, PW; Hecht, SS. (2009a). Clear differences in levels of a formaldehyde-DNA adduct in leukocytes of smokers and nonsmokers. Cancer Res 69: 7170–7174. 10.1158/0008-5472.CAN-09-1571.19738046
Wang, M; Cheng, G; Villalta, PW; SS, H. (2007b). Development of liquid chromatography electrospray ionization tandem mass spectrometry methods for analysis of DNA adducts of formaldehyde and their application to rats treated with N-nitrosodimethylamine or 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone. Chem Res Toxicol 20: 1141–1148. 10.1021/tx700189c.17676814
Wang, R; Zhang, Y; Lan, Q; Holford, TR; Leaderer, B; Zahm, SH; Boyle, P; Dosemeci, M; Rothman, N; Zhu, Y; Qin, Q; Zheng, T. (2009b). Occupational exposure to solvents and risk of non-Hodgkin lymphoma in Connecticut women. Am J Epidemiol 169: 176–185. 10.1093/aje/kwn300.19056833
Wang, T; Pysanenko, A; Dryahina, K; Španěl, P; Smith, D. (2008). Analysis of breath, exhaled via the mouth and nose, and the air in the oral cavity. J Breath Res 2: 1–13. 10.1088/1752-7155/2/3/037013.
Wang, W; Yan, Y; Li, CW; Xia, HM; Chao, SS; Wang, d; Wang, ZP. (2014b). Live human nasal epithelial cells (hNECs) on chip for in vitro testing of gaseous formaldehyde toxicity via airway delivery. Lab Chip 14: 677–680. 10.1039/c3lc51208h.24356185
Wangenheim, J; Bolcsfoldi, G. (1988). Mouse lymphoma L5178Y thymidine kinase locus assay of 50 compounds. Mutagenesis 3: 193–205. 10.1093/mutage/3.3.193.3045481
Wantke, F; Demmer, CM; Tappler, P; Gotz, M; Jarisch, R. (1996a). Exposure to gaseous formaldehyde induces IgE-mediated sensitization to formaldehyde in school-children. Clin Exp Allergy 26: 276–280. 10.1111/j.1365-2222.1996.tb00092.x.8729664
Wantke, F; Focke, M; Hemmer, W; Bracun, R; Wolf-Abdolvahab, S; Götz, M; Jarisch, R; Götz, M; Tschabitscher, M; Gann, M; Tappler, P. (2000). Exposure to formaldehyde and phenol during an anatomy dissecting course: Sensitizing potency of formaldehyde in medical students. Allergy 55: 84–87. 10.1034/j.1398-9995.2000.00307.x.10696862
Wantke, F; Focke, M; Hemmer, W; Tschabitscher, M; Gann, M; Tappler, P; Götz, M; Jarisch, R. (1996b). Formaldehyde and phenol exposure during an anatomy dissection course: A possible source of IgE-mediated sensitization. Allergy 51: 837–841. 10.1111/j.1398-9995.1996.tb00031.x.8947343
Ward, BJ, Jr; Legator, MS; Pereira, MA; Chang, LW. (1983). Evaluation in man and animals of tests for the detection of population exposures to genotoxic chemicals. In MD Waters; SS Sandhu; J Lewtas (Eds.), Short-term bioassays in the analysis of complex environmental mixtures (pp. 461–484). New York, NY: Plenum Press.
Ward, JB, Jr; Hokanson, JA; Smith, ER; Chang, LW; Pereira, MA; Whorton, EB, Jr; Legator, MS. (1984). Sperm count, morphology and fluorescent body frequency in autopsy service workers exposed to formaldehyde. Mutat Res Environ Mutagen Relat Subj 130: 417–424. 10.1016/0165-1161(84)90014-1.
Watanabe, K; Sakamoto, K; Sasaki, T. (1996). Comparisons on chemically-induced mutagenicity among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study I. Mutat Res 361: 143–155. 10.1016/s0165-1161(96)90249-6.8980700
Weber-Tschopp, A; Fischer, T; Grandjean, E. (1977). Reizwirkungen des Formaldehyds (HCHO) auf den Menschen [Irritating effects of formaldehyde on men]. Int Arch Occup Environ Health 39: 207–218. 10.1007/bf00409367.562325
Wei, C; Chen, M; You, H; Qiu, F; Wen, H; Yuan, J; Xiang, S; Yang, X. (2017a). Formaldehyde and co-exposure with benzene induce compensation of bone marrow and hematopoietic stem/progenitor cells in BALB/c mice during post-exposure period. Toxicol Appl Pharmacol 324: 36–44. 10.1016/j.taap.2017.03.024.28373009
Wei, C; Wen, H; Yuan, L; Mchale, CM; Li, H; Wang, K; Yuan, J; Yang, X; Zhang, L. (2017b). Formaldehyde induces toxicity in mouse bone marrow and hematopoietic stem/progenitor cells and enhances benzene-induced adverse effects. Arch Toxicol 91: 921–933. 10.1007/s00204-016-1760-5.27339418
Wei, CN; Harada, K; Ohmori, S; Wei, QJ; Minamoto, K; Ueda, A. (2007). Subjective symptoms of medical students exposed to formaldehyde during a gross anatomy dissection course. Int J Immunopathol Pharmacol 20: 23–25. 10.1177/03946320070200S205.
Wei, H; Tan, K; Sun, R; Yin, L; Zhang, J; Pu, Y. (2014). Aberrant production of Th1/Th2/Th17-related cytokines in serum of C57BL/6 mice after short-term formaldehyde exposure. Int J Environ Res Public Health 11: 10036–10050. 10.3390/ijerph111010036.25264680
Weibel, ER. (1963). Morphometry of the human lung. Berlin, Germany: Springer-Verlag. 10.1007/978-3-642-87553-3.
Weisel, CP; Zhang, J; Turpin, BJ; Morandi, MT; Colome, S; Stock, TH; Spektor, DM; Korn, L; Winer, AM; Kwon, J; Meng, QY; Zhang, L; Harrington, R; Liu, W; Reff, A; Lee, JH; Alimokhtari, S; Mohan, K; Shendell, D; Jones, J; Farrar, L; Maberti, S; Fan, T. (2005). Relationships of indoor, outdoor, and personal air (RIOPA): Part I. Collection methods and descriptive analyses (pp. 1–107; discussion 109–127). (ISSN 1041-5505EISSN 2688-6855 HEI Research Report 130-I, NUATRC Research Report 7). Boston, MA: Health Effects Institute. https://www.proquest.com/scholarly-journals/relationships-indoor-outdoor-personal-air-riopa/docview/70114572/se-2?accountid=171501.
Weisskopf, M; Morozova, N; O’Reilly, EJ; Mccullough, ML; Calle, EE; Thun, MJ; Ascherio, A. (2009). Prospective study of chemical exposures and amyotrophic lateral sclerosis mortality. J Neurol Neurosurg Psychiatry 80: 558–561. 10.1136/jnnp.2008.156976.19372290
Wen, H; Yuan, L; Wei, C; Zhao, Y; Qian, Y; Ma, P; Ding, S; Yang, X; Wang, X. (2016). Effects of combined exposure to formaldehyde and benzene on immune cells in the blood and spleen in Balb/c mice. Environ Toxicol Pharmacol 45: 265–273. 10.1016/j.etap.2016.05.007.27343751
Wesseling, C; Ahlbom, A; Antich, D; Rodriguez, AC; Castro, R. (1996). Cancer in banana plantation workers in Costa Rica. Int J Epidemiol 25: 1125–1131. 10.1093/ije/25.6.1125.9027515
West, GB; Brown, JH. (2005). The origin of allometric scaling laws in biology from genomes to ecosystems: Towards a quantitative unifying theory of biological structure and organization [Review]. J Exp Biol 208: 1575–1592. 10.1242/jeb.01589.15855389
West, S; Hildesheim, A; Dosemeci, M. (1993). Non-viral risk factors for nasopharyngeal carcinoma in the Philippines: Results from a case-control study. Int J Cancer 55: 722–727. 10.1002/ijc.2910550504.7503957
Westberg, H; Löfstedt, H; Seldén, A; Lilja, BG; Nayström, P. (2005). Exposure to low molecular weight isocyanates and formaldehyde in foundries using Hot Box core binders. Ann Occup Hyg 49: 719–725. 10.1093/annhyg/mei040.16126762
WHO (World Health Organization). (1967). Manual of the international statistical classification of diseases, injuries, and causes of death. Geneva, Switzerland.
WHO (World Health Organization). (1977). Manual of the international statistical classification of diseases, injuries, and causes of death. Geneva, Switzerland.
WHO (World Health Organization). (2010). Guidelines for indoor air quality: Selected pollutants. Geneva. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf.
Wilcox, P; Naidoo, A; Wedd, DJ; Gatehouse, DG. (1990). Comparison of Salmonella typhimurium TA102 with Escherichia coli WP2 tester strains. Mutagenesis 5: 285–291. 10.1093/mutage/5.3.285.2200948
Wilhelmsson, B; Holmstrom, M. (1992). Possible mechanisms of formaldehyde-induced discomfort in the upper airways. Scand J Work Environ Health 18: 403–407. 10.5271/sjweh.1556.1485166
Wilkins, RJ; Macleod, HD. (1976). Formaldehyde induced DNA-protein crosslinks in Escherichia Coli. Mutat Res 36: 11–16. 10.1016/0027-5107(76)90016-6.781526
Williams, GM; Mori, H; Mcqueen, CA. (1989a). Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals [Review]. Mutat Res 221: 263–286. 10.1016/0165-1110(89)90039-0.2682231
Williams, JW; Tjota, MY; Sperling, AI. (2012). The contribution of allergen-specific IgG to the development of th2-mediated airway inflammation. J Allergy (Cairo) 2012: 236075. 10.1155/2012/236075.23150737
Williams, RL; Lipari, F; Potter, RA. (1989b). Formaldehyde, methanol, and hydrocarbon emissions from methanol-fueled cars.
Wilmer, JWG, M; Woutersen, RA; Appelman, LM; Leeman, WR; Feron, VJ. (1987). Subacute (4-week) inhalation toxicity study of formaldehyde in male rats: 8-hour intermittent versus 8-hour continuous exposures. J Appl Toxicol 7: 15–16. 10.1002/jat.2550070104.3611592
Wilmer, JWG, M; Woutersen, RA; Appelman, LM; Leeman, WR; Feron, VJ. (1989). Subchronic (13-week) inhalation toxicity study of formaldehyde in male rats: 8-hour intermittent versus 8-hour continuous exposures. Toxicol Lett 47: 287–293. 10.1016/0378-4274(89)90147-1.2749773
Witek, TJ, Jr; Schachter, EN; Tosun, T; Beck, GJ; Leaderer, BP. (1987). An evaluation of respiratory effects following exposure to 2.0 ppm formaldehyde in asthmatics: Lung function, symptoms, and airway reactivity. Arch Environ Health 42: 230–237.3310924
Witek, TJ, Jr; Schachter, EN; Tosun, T; Leaderer, BP; Beck, GJ. (1986). Controlled human studies on the pulmonary effects of indoor air pollution: Experiences with sulfur dioxide and formaldehyde. Environ Int 12: 129–135. 10.1016/0160-4120(86)90023-1.
Wolf, DC; Gross, EA; Lyght, O; Bermudez, E; Recio, L; Morgan, KT. (1995). Immunohistochemical localization of p53, PCNA, and TGF-alpha proteins in formaldehyde-induced rat nasal squamous cell carcinomas. Toxicol Appl Pharmacol 132: 27–35. 10.1006/taap.1995.1083.7747282
Wolff, RK. (1986). Effects of airborne pollutants on mucociliary clearance [Review]. Environ Health Perspect 66: 223–237.3519203
Wong, MA; Isaza, R; Cuthbert, JK; Brooks, DE; Samuelson, D. (2012). PERIOCULAR ANTERIOR ADNEXAL ANATOMY AND CLINICAL ADNEXAL EXAMINATION OF THE ADULT ASIAN ELEPHANT (ELEPHAS MAXIMUS). J Zoo Wildl Med 43: 793–801. 10.1638/2011-0173R2.1.23272346
Wood, RW; Coleman, JB. (1995). Behavioral evaluation of the irritant properties of formaldehyde. Toxicol Appl Pharmacol 130: 67–72. 10.1006/taap.1995.1009.7839371
Wortley, P; Vaughan, TL; Davis, S; Morgan, MS; Thomas, DB. (1992). A case-control study of occupational risk factors for laryngeal cancer. Br J Ind Med 49: 837–844. 10.1136/oem.49.12.837.1472441
Woutersen, RA; Appelman, LM; Wilmer, JWG, M; Falke, HE; Feron, VJ. (1987). Subchronic (13-week) inhalation toxicity study of formaldehyde in rats. J Appl Toxicol 7: 43–49. 10.1002/jat.2550070108.3611596
Woutersen, RA; van Garderen-Hoetmer, A; Bruijntjes, JP; Zwart, A; Feron, VJ. (1989). Nasal tumours in rats after severe injury to the nasal mucosa and prolonged exposure to 10 ppm formaldehyde. J Appl Toxicol 9: 39–46. 10.1002/jat.2550090108.2926095
Wu, LC; Zarrin, AA. (2014). The production and regulation of IgE by the immune system [Review]. Nat Rev Immunol 14: 247–259. 10.1038/nri3632.24625841
Wu, Y; Duan, J; Li, B; Liu, H; Chen, M. (2020). Exposure to formaldehyde at low temperatures aggravates allergic asthma involved in transient receptor potential ion channel. Environ Toxicol Pharmacol 80: 103469. 10.1016/j.etap.2020.103469.32798733
Wu, Y; You, H; Ma, P; Li, L; Yuan, Y; Li, J; Liu, X; Yao, H; Chen, R; Lai, K; Yang, X. (2013). Role of transient receptor potential ion channels and evoked levels of neuropeptides in a formaldehyde-induced model of asthma in Balb/c mice. PLoS ONE 8: e62827. 10.1371/journal.pone.0062827.23671638
Xie, SH; Yu, IT; Tse, LA; Au, JS; Lau, JS. (2017). Occupational risk factors for nasopharyngeal carcinoma in Hong Kong Chinese: a case-referent study. Int Arch Occup Environ Health 90: 443–449. 10.1007/s00420-017-1212-4.28255757
Xin, L; Wang, J; Fan, G; Wu, Y; Guo, S. (2015). Activation of HSPA1A promoter by environmental pollutants: An early and rapid response to cellular damage. Environ Toxicol Pharmacol 39: 1027–1033. 10.1016/j.etap.2015.03.011.25863329
Xing Sy, LY. (2007). Toxic effect of formaldehyde on reproduction and heredity in male mice. Journal of Jilin University - Medicine Edition 33.
Xing, SY; Ye, L; Wang, NN. (2007). Toxic effect of formaldehyde on reproduction and heredity in male mice. Journal of Jilin University - Medicine Edition 33: 716–718.
Yager, JW; Cohn, KL; Spear, RC; Fisher, JM; Morse, L. (1986). Sister-chromatid exchanges in lymphocytes of anatomy students exposed to formaldehyde-embalming solution. Mutat Res 174: 135–139. 10.1016/0165-7992(86)90104-1.3713731
Yan, Y; Ye, Z; Lu, ZS; Qiao, Y; Yang, X; Li, CM. (2005). Nitric oxide level associated with gaseous formaldehyde exposure in lungs of mice. In X Yang; B Zhao; R Zhao (Eds.), Indoor Air 2005: Proceedings of the 10th International Conference on Indoor Air Quality and Climate, vol 5 (pp. 3851–3854). Beijing, China: Tsinghua University Press. https://www.isiaq.org/docs/PDFs/3851.pdf.
Yang, WH. (2007). [Hemogram of workers exposed to low concentration of formaldehyde] (pp. 792–799). Yang, WH.
Yang, X; Zhang, YP; Chen, D; Chen, WG; Wang, R. (2001). Eye irritation caused by formaldehyde as an indoor air pollution--a controlled human exposure experiment. Biomed Environ Sci 14: 229–236.11723723
Yang, XR; Diehl, S; Pfeiffer, R; Chen, CJ; Hsu, WL; Dosemeci, M; Cheng, YJ; Sun, B; Goldstein, AM; Hildesheim, A; Team, CaAGEoNS. (2005). Evaluation of risk factors for nasopharyngeal carcinoma in high-risk nasopharyngeal carcinoma families in Taiwan. Cancer Epidemiol Biomarkers Prev 14: 900–905. 10.1158/1055-9965.EPI-04-0680.15826929
Yang, Y; Luo, H; Liu, R; Li, G; Yu, Y; An, T. (2020). The exposure risk of typical VOCs to the human beings via inhalation based on the respiratory deposition rates by proton transfer reaction-time of flight-mass spectrometer. Ecotoxicol Environ Saf 197: 110615. 10.1016/j.ecoenv.2020.110615.32325328
Ye, X; Ji, Z; Wei, C; Mchale, CM; Ding, S; Thomas, R; Yang, X; Zhang, L. (2013). Inhaled formaldehyde induces DNA-protein crosslinks and oxidative stress in bone marrow and other distant organs of exposed mice. Environ Mol Mutagen 54: 705–718. 10.1002/em.21821.24136419
Ye, X; Yan, W; Xie, H; Zhao, M; Ying, C. (2005). Cytogenetic analysis of nasal mucosa cells and lymphocytes from high-level long-term formaldehyde exposed workers and low-level short-term exposed waiters. Mutat Res 588: 22–27. 10.1016/j.mrgentox.2005.08.005.16257574
Yeatts, KB; El-Sadig, M; Leith, D; Kalsbeek, W; Al-Maskari, F; Couper, D; Funk, WE; Zoubeidi, T; Chan, RL; Trent, CB; Davidson, CA; Boundy, MG; Kassab, MM; Hasan, MY; Rusyn, I; Gibson, JM; Olshan, AF. (2012). Indoor air pollutants and health in the United Arab Emirates. Environ Health Perspect 120: 687–694. 10.1289/ehp.1104090.22357138
Yiamouyiannis, CA; Stengel, PW; Cockerham, SL; Silbaugh, SA. (1995). PULMONARY ACTIONS OF THE NEUROKININ(1)-SPECIFIC AGONIST [SAR(9),MET(O-2)(11)]-SUBSTANCE-P. Neuropeptides 28: 35–42.7538202
Ying, CJ; Yan, WS; Zhao, MY; Ye, XL; Xie, H; Yin, SY; Zhu, XS. (1997). Micronuclei in nasal mucosa, oral mucosa and lymphocytes in students exposed to formaldehyde vapor in anatomy class. Biomed Environ Sci 10: 451–455.9448927
Ying, CJ; Ye, XL; Xie, H; Yan, WS; Zhao, MY; Xia, T; Yin, SY. (1999). Lymphocyte subsets and sister-chromatid exchanges in the students exposed to formaldehyde vapor. Biomed Environ Sci 12: 88–94.10560533
Yokley, KA. (2012). Sensory irritation response in rats II: Recovery and dose-dependence. Bull Math Biol 74: 1673–1690. 10.1007/s11538-012-9730-4.22562388
Yokley, TR. (2009). Ecogeographic variation in human nasal passages. Am J Phys Anthropol 138: 11–22. 10.1002/ajpa.20893.18623075
Yon, DK; Hwang, S; Lee, SW; Jee, HM; Sheen, YH; Kim, JH; Lim, DH; Han, MY. (2019). Indoor Exposure and Sensitization to Formaldehyde among Inner-City Children with Increased Risk for Asthma and Rhinitis. Am J Respir Crit Care Med 200: 388–393. 10.1164/rccm.201810-1980LE.30958969
Yonemitsu, T; Kuroki, C; Takahashi, N; Mori, Y; Kanmura, Y; Kashiwadani, H; Ootsuka, Y; Kuwaki, T. (2013). TRPA1 detects environmental chemicals and induces avoidance behavior and arousal from sleep. Sci Rep 3: 3100. 10.1038/srep03100.24172941
Yoo, SJ; Ito, K. (2018a). Assessment of transient inhalation exposure using in silico human model integrated with PBPK-CFD hybrid analysis. Sustain Cities Soc 40: 317–325. 10.1016/j.scs.2018.04.023.
Yoo, SJ, un; Ito, K. (2018b). Numerical prediction of tissue dosimetry in respiratory tract using computer simulated person integrated with physiologically based pharmacokinetic-computational fluid dynamics hybrid analysis. Indoor Built Environ 27: 877–889. 10.1177/1420326X17694475.
Yorgancilar, E; Deveci, E; Deveci, S. (2012). Effects of formaldehyde on respiratory mucosa in rats. International Journal of Morphology 30: 521–523. 10.4067/S0717-95022012000200026.
Young, JT. (1981). Histopathologic examination of the rat nasal cavity. Fundam Appl Toxicol 1: 309–312. 10.1016/S0272-0590(81)80037-1.6764423
Yu, C; Crump, D. (1998). A review of the emission of VOCs from polymeric materials used in buildings [Review]. Build Environ 33: 357–374. 10.1016/S0360-1323(97)00055-3.
Yu, G; Chen, Q; Liu, X; Guo, C; Du, H; Sun, Z. (2014a). Formaldehyde induces bone marrow toxicity in mice by inhibiting peroxiredoxin 2 expression. Mol Med Rep 10: 1915–1920. 10.3892/mmr.2014.2473.25109304
Yu, GY; Song, XF; Liu, Y; Sun, ZW. (2014b). Inhaled Formaldehyde Induces Bone Marrow Toxicity via Oxidative Stress in Exposed Mice. Asian Pac J Cancer Prev 15: 5253–5257. 10.7314/APJCP.2014.15.13.5253.25040984
Yu, GY; Song, XF; Zhao, SH; Liu, Y; Sun, ZW. (2015a). Formaldehyde induces the bone marrow toxicity in mice by regulating the expression of Prx3 protein. J Huazhong Univ Sci Technolog Med Sci 35: 82–86. 10.1007/s11596-015-1393-6.25673198
Yu, IT; Li, AM; Goggins, W; Leung, JO; Chan, GY; Fung, CK; Chan, CK; Lau, AP. (2017). Association of wheeze during the first 18 months of life with indoor nitrogen dioxide, formaldehyde, and family history of asthma: a prospective cohort study. Hong Kong Med J 23 Suppl 2: 19–23.
Yu, ITS; Chin, YL; Wong, TW; Tang, JL. (2004). Deaths from nasopharyngeal cancer among waiters and waitresses in Chinese restaurants. Int Arch Occup Environ Health 77: 499–504. 10.1007/s00420-004-0543-0.15558301
Yu, LQ; Jiang, SF; Leng, SG; He, FS; Zheng, YX. (2005). Early genetic effects on workers occupationally exposed to formaldehyde. Zhonghua Yufang Yixue Zazhi 39: 392–395.16329798
Yu, PH; Lai, CT; Zuo, DM. (1997). Formation of formaldehyde from adrenaline in vivo; a potential risk factor for stress-related angiopathy. Neurochem Res 22: 615–620. 10.1023/a:1022478221421.9131641
Yu, PH; Zuo, DM. (1996). Formaldehyde produced endogenously via deamination of methylamine. A potential risk factor for initiation of endothelial injury. Atherosclerosis 120: 189–197. 10.1016/0021-9150(95)05701-3.8645360
Yu, R; Lai, Y; Hartwell, HJ; Moeller, BC; Doyle-Eisele, M; Kracko, D; Bodnar, WM; Starr, TB; Swenberg, JA. (2015b). Formation, Accumulation, and Hydrolysis of Endogenous and Exogenous Formaldehyde-Induced DNA Damage. Toxicol Sci 146: 170–182. 10.1093/toxsci/kfv079.25904104
Yu, YH; Blessing, WW. (1997). Cerebral blood flow in rabbits during the nasopharyngeal reflex elicited by inhalation of noxious vapor. J Auton Nerv Syst 66: 149–153. 10.1016/s0165-1838(97)00080-5.9406119
Yu, YH; Blessing, WW. (1999). Amygdala co-ordinates sudden falls in ear pinna blood flow in response to unconditioned salient stimuli in conscious rabbits. Neuroscience 93: 135–141. 10.1016/s0306-4522(99)00097-4.10430478
Zang, ZJ; Fang, YQ; Ji, SY; Gao, Y; Zhu, YQ; Xia, TT; Jiang, MH; Zhang, YN. (2017). Formaldehyde Inhibits Sexual Behavior and Expression of Steroidogenic Enzymes in the Testes of Mice. J Sex Med 14: 1297–1306. 10.1016/j.jsxm.2017.09.001.28943032
Zararsiz, I; Kus, I; Akpolat, N; Songur, A; Ogeturk, M; Sarsilmaz, M. (2006). Protective effects of omega-3 essential fatty acids against formaldehyde-induced neuronal damage in prefrontal cortex of rats. Cell Biochem Funct 24: 237–244. 10.1002/cbf.1204.15648056
Zarei, F; Rezazadeh Azari, M; Salehpour, S; Khodakarim, S; Omidi, L; Tavakol, E. (2017). Respiratory effects of simultaneous exposure to respirable crystalline silica dust, formaldehyde, and triethylamine of a group of foundry workers. Journal of Research in Health Sciences 17: E1–E6.
Zeller, J; Neuss, S; Mueller, JU; Kühner, S; Holzmann, K; Högel, J; Klingmann, C; Bruckner, T; Triebig, G; Speit, G. (2011). Assessment of genotoxic effects and changes in gene expression in humans exposed to formaldehyde by inhalation under controlled conditions. Mutagenesis 26: 555–561. 10.1093/mutage/ger016.21460374
Zendehdel, R; Jouni, FJ; Hajipour, B; Panjali, Z; Kheiri, H; Vahabi, M. (2017). DNA damage in workers exposed to formaldehyde at concentrations below occupational exposure limits. Toxicol Environ Chem 99: 1409–1417. 10.1080/02772248.2017.1343335.
Zendehdel, R; Vahabi, M; Sedghi, R. (2018). Estimation of formaldehyde occupational exposure limit based on genetic damage in some Iranian exposed workers using benchmark dose method. Environ Sci Pollut Res Int 25: 31183–31189. 10.1007/s11356-018-3077-9.30187418
Zhai, L; Zhao, J; Xu, B; Deng, Y; Xu, Z. (2013). Influence of indoor formaldehyde pollution on respiratory system health in the urban area of Shenyang, China. Afr Health Sci 13: 137–143. 10.4314/ahs.v13i1.19.23658580
Zhang, J; He, Q; Lioy, PJ. (1994). Characteristics of aldehydes: Concentrations, sources, and exposures for indoor and outdoor residential microenvironments. Environ Sci Technol 28: 146–152. 10.1021/es00050a020.22175844
Zhang, J; Sun, R; Chen, Y; Tan, K; Wei, H; Yin, L; Pu, Y. (2014a). Small molecule metabolite biomarker candidates in urine from mice exposed to formaldehyde. International Journal of Molecular Sciences 15: 16458–16468. 10.3390/ijms150916458.25233128
Zhang, L; Tang, X; Rothman, N; Vermeulen, R; Ji, Z; Shen, M; Qiu, C; Guo, W; Liu, S; Reiss, B; Freeman, LB; Ge, Y; Hubbard, AE; Hua, M; Blair, A; Galvan, N; Ruan, X; Alter, BP; Xin, KX; Li, S; Moore, LE; Kim, S; Xie, Y; Hayes, RB; Azuma, M; Hauptmann, M; Xiong, J; Stewart, P; Li, L; Rappaport, SM; Huang, H; Fraumeni, JF, Jr; Smith, MT; Lan, Q. (2010). Occupational exposure to formaldehyde, hematotoxicity, and leukemia-specific chromosome changes in cultured myeloid progenitor cells. Cancer Epidemiol Biomarkers Prev 19: 80–88. 10.1158/1055-9965.EPI-09-0762.20056626
Zhang, Q; Yan, W; Bai, Y; Zhu, Y; Ma, J. (2014b). Repeated formaldehyde inhalation impaired olfactory function and changed SNAP25 proteins in olfactory bulb. Int J Occup Environ Health 20: 308–312. 10.1179/2049396714Y.0000000079.25131264
Zhang, S; Chen, H; Wang, A; Liu, Y; Hou, H; Hu, Q. (2018a). Combined effects of co-exposure to formaldehyde and acrolein mixtures on cytotoxicity and genotoxicity in vitro. Environ Sci Pollut Res Int 25: 25306–25314. 10.1007/s11356-018-2584-z.29946839
Zhang, S; Chen, H; Zhang, J; Li, J, un; Hou, H; Hu, Q. (2020a). The multiplex interactions and molecular mechanism on genotoxicity induced by formaldehyde and acrolein mixtures on human bronchial epithelial BEAS-2B cells. Environ Int 143: 105943. 10.1016/j.envint.2020.105943.32659531
Zhang, S; Zhang, J; Chen, H; Wang, A; Liu, Y; Hou, H; Hu, Q. (2019). Combined cytotoxicity of co-exposure to aldehyde mixtures on human bronchial epithelial BEAS-2B cells. Environ Pollut 250: 650–661. 10.1016/j.envpol.2019.03.118.31035147
Zhang, S; Zhang, J; Cheng, W; Chen, H; Wang, A; Liu, Y; Hou, H; Hu, Q. (2020b). Combined cell death of co-exposure to aldehyde mixtures on human bronchial epithelial BEAS-2B cells: Molecular insights into the joint action. Chemosphere 244: 125482. 10.1016/j.chemosphere.2019.125482.31812766
Zhang, X; Zhao, Y; Song, J; Yang, X; Zhang, J; Zhang, Y; Li, R. (2018b). Differential health effects of constant versus intermittent exposure to formaldehyde in mice: Implications for building ventilation strategies. Environ Sci Technol 52: 1551–1560. 10.1021/acs.est.7b05015.29293324
Zhang, Y; Liu, X; Mchale, C; Li, R; Zhang, L; Wu, Y; Ye, X; Yang, X; Ding, S. (2013). Bone marrow injury induced via oxidative stress in mice by inhalation exposure to formaldehyde. PLoS ONE 8: e74974. 10.1371/journal.pone.0074974.24040369
Zhao, MY; Ying, CJ; Shao, N; Yang, Y; Yang, CF; Shi, L; Liu, WQ. (1994). The study of health effects of vinyl chloride air pollution on population. Biomed Environ Sci 7: 136–143.7946009
Zhao, W; Guangyin, P; Yang, X. (2009). DNA-protein crosslinks induced by formaldehyde and its repair process. Int J Environ Pollut 37: 299–308.
Zhao, Y, un; Magana, LC; Cui, H; Huang, J; Mchale, CM; Yang, X, u; Looney, MR; Li, R, ui; Zhang, L. (2020). Formaldehyde-induced hematopoietic stem and progenitor cell toxicity in mouse lung and nose. Arch Toxicol 95: 693–701. 10.1007/s00204-020-02932-x.33084937
Zheng, W; Blot, WJ; Shu, XO; Diamond, EL; Gao, YT; Ji, BT; Fraumeni, J. R. (1992). A population-based case-control study of cancers of the nasal cavity and paranasal sinuses in Shanghai. Int J Cancer 52: 557–561. 10.1002/ijc.2910520410.1399136
Zhitkovich, A; Costa, M. (1992). A simple, sensitive assay to detect DNA-protein crosslinks in intact cells and in vivo. Carcinogenesis 13: 1485–1489. 10.1093/carcin/13.8.1485.1499101
Zhong, W; Hee, SQ. (2004). Quantitation of normal and formaldehyde-modified deoxynucleosides by high-performance liquid chromatography/UV detection. Biomed Chromatogr 18: 462–469. 10.1002/bmc.337.15340972
Zhong, W; Que Hee, SS. (2004). Formaldehyde-induced DNA adducts as biomarkers of in vitro human nasal epithelial cell exposure to formaldehyde. Mutat Res 563: 13–24. 10.1016/j.mrgentox.2004.05.012.15324745
Zhou, D; Zhang, J; Wang, H. (2011a). Assessment of the potential reproductive toxicity of long-term exposure of adult male rats to low-dose formaldehyde. Toxicol Ind Health 27: 591–598. 10.1177/0748233710393401.21357637
Zhou, D; Zhang, J; Wang, H; Xue, Y. (2011b). Effect of formaldehyde exposure on structure and function of epididymis in adult rats: A histological and biochemical study. Toxicol Environ Chem 93: 134–144. 10.1080/02772248.2010.501145.
Zhou, DX; Qiu, SD; Zhang, J; Tian, H; Wang, HX. (2006). The protective effect of vitamin E against oxidative damage caused by formaldehyde in the testes of adult rats. Asian J Androl 8: 584–588. 10.1111/j.1745-7262.2006.00198.x.16751993
Zhou, ES; Kane, YY; Gao, XX; Wu, LF; Lu, ZS; Yan, Y; Qiao, Y; Yang, X. (2005). A pilot investigation on human serum formaldehyde-specific IgE. Paper presented at 10th International Conference on Indoor Air Quality and Climate, September 4-9, 2005, Beijing, China.
Zhu, JL; Knudsen, LE; Andersen, AM; Hjollund, NH; Olsen, J. (2005). Time to pregnancy among Danish laboratory technicians who were a part of the National Birth Cohort. Scand J Work Environ Health 31: 108–114.15864904
Zhu, JL; Knudsen, LE; Andersen, AM; Hjollund, NH; Olsen, J. (2006). Laboratory work and pregnancy outcomes: a study within the National Birth Cohort in Denmark. Occup Environ Med 63: 53–58. 10.1136/oem.2005.021204.16361406
Zimmermann, FK; Mohr, A. (1992). Formaldehyde, glyoxal, urethane, methyl carbamate, 2,3-butanedione, 2,3-hexanedione, ethyl acrylate, dibromoacetonitrile and 2-hydroxypropionitrile induce chromosome loss in Saccharomyces cerevisiae. Mutat Res 270: 151–166. 10.1016/0027-5107(92)90126-M.1383732
Zitting, A; Savolainen, H; Nickels, J. (1982). Biochemical and toxicological effects of single and repeated exposures to polyacetal thermodegradation products. Environ Res 29: 287–296. 10.1016/0013-9351(82)90031-7.7160348
Zwart, A; Woutersen, RA; Wilmer, JWG, M; Spit, BJ; Feron, VJ. (1988). Cytotoxic and adaptive effects in rat nasal epithelium after 3-day and 13-week exposure to low concentrations of formaldehyde vapour. Toxicology 51: 87–99. 10.1016/0300-483X(88)90083-2.3413803