# APPENDIX G ASSESSMENTS BY OTHER NATIONAL AND INTERNATIONAL HEALTH AGENCIES

Table G-1 Hazard conclusions and toxicity values developed by other national and international health agencies

Organization | Conclusions and toxicity values
Agency for Toxic Substances and Disease Registry (ATSDR, 1999) | Chronic inhalation minimal risk levels (MRL) = 0.008 ppm using a composite uncertainty factor (UF) of 30, based on clinical symptoms of irritation of eyes and upper respiratory tract and mild damage to the nasal epithelium in chronically exposed workers (Holmstrom et al., 1989c); Intermediate MRL = 0.03 ppm using composite UF of 30 based on nasopharyngeal irritation in Cynomolgus monkeys (Rusch et al., 1983); Acute MRL = 0.04 ppm using UF = 9 based on nasal and eye irritation in human volunteers (Pazdrak et al., 1993).
Interim Acute Exposure Guideline Levels (AEGLs) for Formaldehyde,National Advisory Committee for AEGLs for Hazardous Substances (NAC/AEGL, 2008) | AEGL-1 (nondisabling)—0.90 ppm (1.1 mg/m^3^) for exposures ranging from 10 min to 8 hr to protect against mild irritation, based on mild irritation in human subjects.; AEGL-2 (disabling)—14 ppm (17 mg/m^3^) for exposures ranging from 10 min to 8 hr to protect against mild lacrimation with adaptation in humans.; AEGL-3 (lethal)—100 ppm (123 mg/m^3^) for a 10-min exposure to 35 ppm (43 mg/m^3^) for an 8-hr exposure, the highest nonlethal values in the rat.
National Toxicology Program (NTP, 2011b) | Known to be a human carcinogen based on sufficient evidence of carcinogenicity from studies in humans (consistent findings for nasopharyngeal, sinonasal, and myeloid leukemia) and supporting data on mechanisms of carcinogenesis (NTP, 2011b).
National Institute of Occupational Safety and Health (NIOSH, 2011, https://www.cdc.gov/niosh/idlh/50000.html) | Potential occupational carcinogen. Recommended exposure limit (REL)—0.016 ppm (0.04 mg/m^3^) TWA for up to a 10-hr workday and a 40-hr work wk.
Occupational Safety and Health Standard 1910.1048 | Permissible exposure limit (PEL) for general industry—0.75 ppm (0.92 mg/m^3^) TWA for an 8-hr workday; Short-term exposure limit: 2 ppm (2.5 mg/m^3^), 15-min duration.
International Agency for Research on Cancer, Monograph Vol. 88 (IARC, 2006); Monograph Vol. 100F (IARC, 2012) | Sufficient evidence in humans for the carcinogenicity of formaldehyde based on nasopharyngeal cancer and leukemia (Group 1). Sufficient evidence in experimental animals for the carcinogenicity of formaldehyde.
European Union, European Commission, Scientific Committee on Occupational Exposure Limits (SCOEL, 2017) | Carcinogen group C: genotoxic carcinogen with a mode-of-action-based threshold. Occupational exposure limit (OEL)—8h-TWA of 0.3 ppm (0.369 mg/m^3^); STEL 15 min of 0.6 ppm (0.738mg/m^3^) based on cytotoxic irritation in studies of human volunteers.
Health Canada (2006, https://www.canada.ca/en/health-canada/services/publications/healthy-living/residential-indoor-air-quality-guideline-formaldehyde.html) Residential Indoor Air Quality Guideline | Short-term exposure: 123 μg/m^3^ (1-hr average) based on eye, nose, and throat irritation (Kulle, 1993); long-term exposure: 50 μg/m^3^ (8-hr average) based on respiratory symptoms in children with asthma (Rumchev et al., 2002).
(Health Canada, 2001) Priority Substances List Assessment Report | The inhalation of formaldehyde under conditions that induce cytotoxicity and sustained regenerative proliferation is considered to present a carcinogenic hazard to humans.