# APPENDIX F RESPONSE TO EXTERNAL COMMENTS

The IRIS Toxicological Review of Formaldehyde(Inhalation) has undergone a formal external peer review by the National Academy of Sciences, Engineering, and Medicine (NASEM) in accordance with U.S. Environmental Protection Agency (EPA) guidance on peer review (U.S. EPA, 2015). Multiple public, external peer-review meetings were held on 10/12–10/13/2022, 12/22/2022, and 1/30–1/31/2023, each of which included an opportunity for public comment. The public was also able to submit written comments to NASEM throughout the peer review. The NASEM peer review panel was tasked with providing consensus comments on the assessment approaches, key conclusions, and areas of scientific controversy or uncertainty. Supplementing the general statement of task NASEM provided to the panel (see below), EPA provided the panel with a series of charge questions (posted to the IRIS website, https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=248150, and the public docket, https://www.regulations.gov/docket/EPA-HQ-ORD-2010-0396) to help guide the panel’s review. Prior to the external peer review, the assessment was released for public comment (04/14/2022), Step 4a of the IRIS process. Public comments were submitted to the U.S. EPA docket by 06/13/2022.

NASEM Statement of Task (Box S-1 of the NASEM report): An ad hoc committee under the auspices of the National Academies of Sciences, Engineering, and Medicine will conduct a scientific review of EPA’s draft document referred to as the Integrated Risk Information System (IRIS) Toxicological Review of Formaldehyde, plus appendices. The committee will assess whether EPA’s draft document adequately and transparently evaluated the scientific literature, used appropriate methods to synthesize the current state-of-the science, and presented conclusions regarding the hazard identification analysis and dose-response analysis of formaldehyde that are supported by the scientific evidence. The committee will not conduct its own hazard assessment of formaldehyde, nor will the committee address the broader aspects of the IRIS Program.

The comments made by the external peer reviewers and public commenters, as well as EPA’s responses to these comments, are grouped according to the chapters and topic areas identified in the NASEM peer review report and bulleted below. The relevant EPA charge questions provided to the panel are also reiterated for each topic area. The consensus “findings” and tiered recommendations (see tiering description below) are directly quoted from the body of the NASEM consensus study report (see https://www.nationalacademies.org/our-work/review-of-epas-2022-draft-formaldehyde-assessment); topics without findings or recommendations are not included in this Appendix. In some cases, content from the NASEM study report’s Appendices is included to note more specific or supplemental advice. Along with the relevant EPA charge questions, a summary of the number of findings and recommendations from the panel on each topic area is provided at the start of each section. The reader is encouraged to consult the report in its entirety.

Public comments submitted to the EPA docket are included within each relevant topic area (including an additional “other public comments” section for general comments and comments on topics not highlighted in the NASEM report). Where public comments were made on topics raised by the external peer reviewers, they are noted along with the external peer review comments. When comments from the public and peer review panel on a topic differed, the recommendations of the panel are prioritized. As needed, additional public comments not fitting within the topics outlined by the peer reviewers are included in a separate section at the end of each chapter-based section. As the public comments received in the docket were voluminous, EPA previously developed an organized summary of the comments received and provided this summary to the panel at the beginning of the peer review and posted it in the docket. This summary compilation was used to populate the public comments in this Appendix. The summary includes indexing to the specific documents and page numbers for the quoted comments below. Please note that this summary did not include public comments provided directly to NASEM after announcing the external peer review in 2022 or comments submitted to the EPA docket regarding the length of the public comment period or a requested correction to an affiliation. In this summary, some comments were truncated for brevity^42^; the reader is encouraged to consult the EPA docket for the full text of the public comments received: https://www.regulations.gov/docket/EPA-HQ-ORD-2010-0396).

External Peer Reviewers were asked to prioritize their comments to indicate their relative importance as follows (these instructions are duplicated from the charge questions and NASEM report):

- Tier 1: Necessary Revisions – Please use this category for any revisions you believe are necessary to adequately support and substantiate the assessment conclusions in the formaldehyde (inhalation) assessment. For Tier 1 recommendations, please clearly describe and justify each necessary revision.
- Tier 2: Suggested Revisions – Please use this category for any revisions you encourage EPA to implement to strengthen the analyses or scientific basis for the assessment conclusions, or to improve the clarity of the presentation in the formaldehyde (inhalation) assessment.
- Tier 3: Future Considerations – Please use this category for any advice you have for scientific exploration that might inform future work. While these recommendations are generally outside the immediate scope or needs of the formaldehyde (inhalation) assessment, they could inform future assessments or research efforts.

Tier 1 Recommendations and Tier 2 Suggestions were considered taking into account the extent to which those suggestions would impact the conclusions or quantitative analyses in the assessment and the level of effort to implement. For this assessment, all Tier 1 and Tier 2 suggestions were addressed or implemented. Tier 3 Future Considerations are generally outside of the immediate scope or need of the Toxicological Review but may inform future analyses; two of the four Tier 3 considerations received from peer reviewers on this assessment were addressed or implemented (see below). Most of the Findings and general comments received did not require an EPA response.

External peer reviewer and public comments regarding requests for additions of clarifying text or editorial or grammatical corrections have been made throughout the assessment as appropriate; these comments and responses have not been tracked in this Appendix.

## F.1 NASEM REPORT CHAPTER 2: “METHODS AND ORGANIZATION”; CHARGE QUESTION 1: ASSESSMENT DEVELOPMENT METHODS AND ORGANIZATION

### F.1.1 Charge Question(s) and Peer Review Comment Summary

#### Charge Question 1: Assessment Development Methods and Organization

The Toxicological Review describes and applies a systematic review process for identifying, screening, and evaluating pertinent studies, and then for prioritizing the evidence to inform hazard and dose-response decisions. This process is described in the Toxicological Review’s Preface on Assessment Methods and Organization, with documentation primarily in Appendix A.5 [Appendix B in the revised assessment]. Please answer parts (a) and (b).

a. Please comment on whether the methods for assessment development (Preface on Assessment Methods and Organization) and the organization of the assessment are clear and transparent.
b. Please comment on whether there is sufficient documentation on methods and criteria for the following:
  - Identification of epidemiologic, experimental, and mechanistic studies (please identify any additional peer-reviewed studies that would significantly alter key assessment conclusions and thus should be incorporated prior to finalization)^43^.
  - Critical evaluation of individual studies or sets of studies.
  - Assessment of the weight of evidence (i.e., evidence integration).
  - Selection of studies and data sets for deriving toxicity values.

#### Peer Review Comment Summary

- 1 Tier 1 Recommended Revision
- 7 Tier 2 Suggested Revisions (2 have multiple parts)
- 0 Tier 3 Future Considerations
- 14 Consensus Panel Findings (numbered below) and 1 Conclusion

### F.1.2 Response to Prior National Research Council (NRC) Reports

#### Peer Review Findings and Comments

- Finding (1): The 2022 Draft Assessment responds to the broad intent of the 2011 NRC report.
- Finding (2): The 2022 Draft Assessment is responsive to the broad intent of the 2011 NRC review of EPA’s 2010 Draft Assessment and the 2014 NRC review of the IRIS process.

#### Related Public Comments

- Public Comment (University of California San Francisco): “The extent to which EPA has addressed the 2011 NAS recommendations is unclear. We are generally concerned with whether the 2011 NAS recommendations for the formaldehyde assessment were fully taken into consideration in this assessment. Given the critical feedback from the NAS, we were surprised to see that the NAS report is rarely mentioned in the draft Formaldehyde Toxicological Review. It would be appropriate to more thoroughly outline how changes to the assessment were incorporated to address the concerns raised by this committee of experts.”
- Public Comment (Troy Corporation): “Based on the 2010 National Academy of Sciences (NAS) IRIS formaldehyde review and their 2011 recommendations to the EPA it [is] difficult to discern if these were followed in the preparation of the current assessment. The 2010 NAS document clearly indicated EPA did not identify modes of action and failed to utilize a “weight of evidence” approach towards endpoints such as nasal pharyngeal cancer (NPC), sino-nasal cancer, lymphohematopoietic cancer (LHP), nervous system effects and systemic toxicity. Unfortunately, the 2022 IRIS assessment also did not follow these recommendations and many of the conclusions for these endpoints are the same as in 2010.”

EPA Response (to both public comments above): The responses and actions made in response to the NAS (2011) comments were provided in Appendix D of the external review draft. Please see the consensus peer review panel findings on this topic from the external peer review panel above, which finds the 2022 draft to be broadly responsive to prior NAS recommendations.

### F.1.3 Alignment of the Assessment Methods with the State of Practice

#### Approach to Documentation of Methods

##### Peer Review Findings and Comments

- Finding (3): EPA did not develop a set of specific protocols for the 2022 Draft Assessment in a fashion that would be consistent with the general state of practice that evolved during the prolonged period when the assessment was being developed. Instead, EPA described the assessment methods across the three documents that together make up the 2022 Draft Assessment: The Main Assessment (789 pages), accompanying Appendices (1059 pages), and an Assessment Overview (192 pages).
- NASEM Panel Conclusion: Pre-published protocols are essential for future IRIS assessments to ensure transparency for systematic reviews in risk assessment.

EPA Response to Finding 3 and the Conclusion: Although no action is necessary for the IRIS formaldehyde assessment, EPA agrees with the Conclusion regarding future IRIS assessments. As noted in the consensus peer review report, “the procedures used by the IRIS Program were evolving over the period during which the 2022 Draft Assessment was being developed. The IRIS Handbook, which would provide detailed and codified guidance for developing IRIS assessments and make the IRIS process transparent to stakeholders…was released in draft in 2020 and finalized in 2022…Further, work on the 2022 Draft Assessment was suspended in 2018 after the draft’s completion in 2017…The use of prereview—i.e., publicly released—protocols to document the methods to be used in an IRIS systematic review began in 2018 (EPA, 2018).” Since 2018, the IRIS Program has published more than a dozen assessment protocols.

- Finding (4): The committee’s review of the 2022 Draft Assessment documents the challenges faced by users of the assessment in navigating the voluminous documentation and understanding the methods used and evidence assessed. EPA needs to revise the Draft Assessment to ensure that the methods used for each outcome can easily be found by providing a linked roadmap and merging the descriptions of the methods used for each outcome in a single location.
- Tier 1 Recommended Revision (Recommendation 2.1): EPA should revise its assessment to ensure that users can find and follow the methods used in each step of the assessment for each health outcome. EPA should eliminate redundancies by providing a single presentation of the methods used in the hazard identification and dose-response processes. A central roadmap and cross-references are also needed to facilitate access to related sections across the different elements of the assessment (e.g., appendixes, main document) for the different outcomes analyzed.

EPA Response to Tier 1 Recommended Revision 2.1: The revised assessment incorporates extensive changes and additions in response to this recommendation. Some of the most notable revisions are bulleted below.

- A single assessment methods section (Section 2 in the revised Toxicological Review) akin to a Protocol, stating all the methods used in the assessment, has been added to the beginning of the Toxicological Review. The methods describe both the general methods applied based on study type (e.g., epidemiology studies) as well as by topic area (e.g., sensory irritation).
- The Appendices have been revised to have a complementary presentation to the Assessment Methods section. The revised Appendices are now the location for the transparent documentation of the application of those methods (e.g., literature search and study evaluation in Appendix B of the revised assessment) to the identified studies on each health effect- and mechanism-specific topic area.
- A document map has been added to the assessment methods, and cross-referencing to topic-specific methods has been added throughout the Toxicological Review.
- The Assessment Overview has not been retained (please note that the intent of this document was to briefly summarize the findings from the Toxicological Review, not serve as a separate piece of analysis).
- For the literature searches, the methods and documentation have been revised to improve clarity and transparency as follows:
  ○ The PECO criteria for each search were clarified and now have a consistent presentation in the assessment methods, with explanations provided for many of the specific inclusion/exclusion criteria. The language used to describe specific inclusion or exclusion criteria has been standardized across health effects-study type.
  ○ A new, streamlined HERO page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/4051) for documentation of screening decisions was developed, providing documentation more consistent with current practice within the IRIS Program.
  ○ The documentation of the search results for a given health effect- or mechanism-specific search (including electronic searches and the systematic evidence map-based results) have been consolidated by topic area in both Appendix B and in the HERO page.
- For the study evaluations, the following changes were made:
  ○ The Study Evaluation section begins with an overview (Section 2.3.1 in the revised assessment) describing the commonalities in the approaches used across study types for the overall study confidence classification (high, medium, low, not informative), and the domain-specific classifications (Good, Adequate, Deficient).
  ○ The Study Evaluation overview section also includes a discussion of the evaluation criteria and classification scheme used for three major study types. A summary of the approach use for mechanistic studies is also included in this overview section. The criteria covered for each study type include:
    ■ For observational epidemiology studies: Population selection, Information bias (relating to outcome classification and exposure measurement in residential and school settings and in occupational settings), potential for confounding, analytic approach, and other sensitivity considerations;
    ■ For experimental studies in animals: Exposure quality, test subjects, study design, endpoint evaluation, and data considerations and statistics; and
    ■ For controlled exposure studies in humans: Exposure assessment, outcome classification, consideration of potential observer and subject bias, consideration of confounding, and results presentation.
  ○ This overview section is followed by domain-specific sections describing the application of the evaluation criteria described in the overview. The criteria are presented in a tabular format and now more transparently describe how ‘good’, ‘adequate’ and ‘deficient’ ratings are drawn for each domain based on general and topic area-specific considerations.
  ○ To enhance consistency in documentation of study evaluations, the documentation tables (now in Appendix B.3) were revisited to ensure the criteria were consistently applied, both within a topic area and across studies of similar type (e.g., in vivo experimental animal studies).
  ○ The graphics (“caterpillars”) previously included to summarize the judgments for epidemiology studies were removed and replaced with simplified text and documentation (e.g., shading of domains resulting in lower confidence ratings) that more directly map to the evaluated domains.
- Evidence synthesis approaches have been revised as follows:
  ○ Synthesis judgments are now included for each evidence stream, separate from evidence integration judgments.
  ○ Each synthesis section includes a brief recap of the methods used, as well as increased cross-referencing, and a listing of studies that met PECO criteria but were classified as not informative and thus not synthesized.
  ○ Each synthesis section is summarized in bullets documenting the considerations (i.e., modified Bradford-Hill considerations) and formaldehyde-specific data that were most influential to the evidence synthesis judgment.
  ○ Evidence synthesis summary judgments are drawn and presented during evidence synthesis rather than only as a component of evidence integration.
  ○ Several synthesis sections not impacting the primary assessment conclusions (e.g., acute and short-term exposure impacts on pulmonary function; attempts to estimate a unit risk for myeloid leukemia) are now briefly summarized in the Toxicological Review, with the more detailed analyses moved to the Appendices.
- Evidence integration approaches and documentation have been revised as follows:
  ○ The evidence profile tables have been revised and now separately present the evidence-based factors that increased or decreased certainty within and across the evidence streams.
  ○ Terms including ‘other inferences’ and ‘relevant exposure circumstances’ (now “sufficient exposure conditions”) are more clearly defined and contextualized.
- The dose-response methods and documentation have also been significantly revised, including:
  ○ A table of more detailed methods for selecting studies for dose-response analysis has been added to the assessment methods (Section 2.7 in the revised Toxicological Review).
  ○ Individual tables documenting the rationale for advancing certain formaldehyde-specific studies for dose-response analysis (based on the methods laid out in Section 2.7) have been added for each health effect with a strong enough hazard judgment to support dose-response analysis in Section 5.
  ○ Modeling for many of the studies advanced for dose-response analysis has been re-performed or confirmed using updated methods (e.g., using the current version of BMDS).

- Tier 2 Suggested Revision (Recommendation 2.2): In updating the assessment in line with the Tier 1 Recommendation 2.1, EPA should further clarify the evidence review and conclusions for each health outcome by giving attention to the following:
  ○ [2.2 a] Using a common outline to structure the sections for each health outcome in order to provide a coherent organization that has a logical flow, by adding an overview paragraph to guide readers at the start of sections for each of the various health domains, and including hyperlinks to facilitate cross-walking among sections within the document;
  ○ [2.2 b] Moving lengthy, not directly used information to an appendix;
  ○ [2.2 c] Including a succinct executive summary in the Main Assessment; and
  ○ [2.2 d] Performing careful review and technical editing of the documents for consistency across the multiple parts of the Draft Assessment, including across the Assessment Overview and Appendices. (The Assessment Overview could be entirely removed if the above recommendations were carried out.)

EPA Response to Tier 2 Suggested Revision 2.2: EPA has revised the assessment as follows:

- [2.2a] Summaries following a consistent format provide an overview for each section and include callouts to the relevant methods. The cancer sections are structured identically, based on considerations outlined in the EPA cancer guidelines (U.S. EPA, 2005). In addition, for both noncancer and cancer health effects, summary sections recapping the evidence synthesis judgments were added after each synthesis piece, based on each Hill consideration impactful to the judgments.
- [2.2b] Several synthesis sections not impacting the primary assessment conclusions (e.g., acute, and short-term exposure impacts on pulmonary function; attempts to estimate a unit risk for myeloid leukemia) were moved to the Appendices and are now only briefly summarized in the Toxicological Review.
- [2.2c] The Executive Summary at the beginning of the Toxicological Review provides a succinct summary of the key assessment conclusions and their basis.
- [2.2d] The documents have been edited for clarity and consistency. The Assessment Overview, which was not intended as a separate document of EPA analyses but rather as a summary of the main messages from the analyses presented in the Toxicological Review, has not been retained as part of the revised assessment.

- Un-Tiered, related peer review comments (Appendix E): Several clarifications and corrections on this topic were noted in Appendix E, including:
  ○ [a] “In some cases, Tables and Figures included in the Appendices are not cited in other documents (e.g., Figures A-24 to A-26).”
  ○ [b] “As an example of inconsistencies that EPA needs to address, Figure A-36 shows 20 human studies and 35 animal studies for inclusion. Table A-93, which summarizes the animal data for developmental and reproductive toxicity and animal studies, contains 29 rows, with one row containing two studies (Vosoughi et al., 2012, 2013), resulting in 30 total animal studies (not 35 as stated in Figure A-36).”
  ○ [c] “EPA needs to document whether the evidence integration summary tables in the Main Assessment and Assessment Overview are identical.”
  ○ [d] “Figure 2-3 needs to be modified to more accurately show representative ranges of outdoor and indoor formaldehyde concentrations.

EPA Response to Un-Tiered Comment: The following changes were incorporated.

- [a] EPA has reviewed the Tables and Figures to ensure they are called out in the text.
- [b] EPA has reviewed and clarified a number of inconsistencies, particularly related to counts of identified literature.
- [c] The Assessment Overview has not been retained in the revised assessment.
- [d] The figure referenced (in Section 5.1.5 of the revised Toxicological Review) has been revised and no longer presents estimates of ranges of outdoor and indoor formaldehyde concentrations. A summary of estimates of the median levels of formaldehyde in homes and outdoor air has been added to the text for context.

##### Related Public Comments

- Public Comment (University of California San Francisco): ““EPA did not clearly develop a pre-published protocol. EPA, in its Charge Questions to the Peer Review Committee, stated that ‘The IRIS Program decided to conduct a reassessment of formaldehyde inhalation from scratch on the basis of that review, using transparent and predefined systematic review methods.’ We are deeply concerned that we were unable to find an IRIS Assessment Plan or Protocol released in advance of the assessment for peer review comment. Although there were myriad delays of this document, it is troubling that such a protocol may not have been released, which violates the IRIS process for conducting assessments and the stated intent to used ‘transparent and predefined systematic review methods.’ We have commented extensively on the importance of pre-defined protocols, which are foundational to such assessments and play an important role in reducing bias and ensuring transparency.”
- Public Comment (American Chemistry Council): “In developing the 2022 Draft Assessment, EPA failed to fully implement this first step. EPA never released an IRIS assessment plan, which would have included scoping and problem formulation materials. Rather, on its website it states that this step is “not applicable” without explaining why this step is not applicable. By not following the IRIS process, EPA denied the public multiple opportunities to provide valuable input into key formative elements of the 2022 Draft Assessment. Consequently, the 2022 Draft Assessment was not based on a fully developed record of available information.”
  “The 2022 Draft Assessment does not discuss scoping or problem formulation activities for the “newly developed” assessment…Consistent with the recommendations from the NASEM (2011) review of the 2010 Draft Assessment, EPA should have engaged in an explicit scoping and problem formulation process to specifically address best available evidence-based health outcomes in the context of mode of action.”
  “…The 2022 draft Formaldehyde Review contains no discussion of problem formulation activities or an Assessment Plan. There is very little discussion of how EPA arrived at the Populations, Exposures, Comparators, and Outcomes (PECO) statements, and no discussion of EPA’s hypotheses regarding critical endpoints for formaldehyde assessment. To meet the NASEM recommendations, EPA should have organized the draft Formaldehyde Review around plausible MOAs and/or hypotheses regarding the most critical formaldehyde effects. At a minimum, EPA should revise the draft to include discussion regarding problem formulation and scoping activities that occurred in 2012 and again in 2021, particularly considering the many changes to the IRIS Program in the 10 years between initiation of the assessment and its release.”
  “For example, EPA has not planned, issued, nor taken comment on a systematic review protocol for formaldehyde, unlike the other sixteen chemicals to be assessed according to the Agency’s February 2022 IRIS Program Outlook. However, the Feb. 8 EPA letter claims that “[t]he systematic review methods used in the current draft IRIS formaldehyde assessment formed the basis for the methods presented in the IRIS Handbook, which was favorably reviewed by the NASEM in November 2021.” While subsequent process-oriented reviews may offer context to the panel reviewing the 2022 IRIS assessment, they do not resolve NASEM critiques of the previous IRIS assessment of formaldehyde.” [Please see docket for details and supporting information.]

EPA Response (to both public comments above): NAS (2011) understood implementing SR methods would take years and made it clear that EPA should not wait until SR is fully implemented to produce IRIS assessments. With respect to formaldehyde specifically, “The committee recognizes that revision of the approach will involve an extensive effort by EPA staff and others, and it is not recommending that EPA delay the revision of the formaldehyde assessment to implement a new approach.” SR enhancements such as releasing IRIS Assessment Plans (IAPs) and protocols, are a relatively recent activities (begun in 2017 and 2018, respectively). The current formaldehyde draft was in progress well before this timeframe. While EPA did not publicly release a protocol prior to initiating the current draft, the methods previously described in the Preface (now in a standalone “Assessment Methods” section) and used to develop the draft are consistent with the current SR methods outlined in the IRIS Handbook, which has been peer-reviewed by NASEM. Further, the key science issues and chemical-specific considerations that IRIS assessment protocols describe were detailed in NAS’s (2011) report, which directly informed the current draft. EPA Note: Some recommendations attributed to NAS (2011) in the public comments above (e.g., on a process for scoping and problem formulation) could not be confirmed after consulting the 2011 report.

#### Evidence Identification (Steps 1 and 2)

##### Peer Review Findings and Comments

- Finding (5): EPA’s literature search strategies for the 2022 Draft Assessment are adequate and consistent with the state of practice at the time. EPA appears to have sufficiently harmonized the methods for the pre- and post-2016 literature searches that were conducted using two different methods and were consistent with the state of practice at the time. Although the search strategies are adequately documented, the origins of the various PECO statements are less clear. In particular, across noncancer outcomes, the rationale for study exclusion on the basis of the populations, exposures, and outcomes is not well documented. For the literature searches, EPA used four databases, curated reference lists in published reviews, and “other national or international health assessments of formaldehyde,” consistent with prior NASEM guidance (See Appendix C [case study: Hanrahan et al., 1984, human sensory irritation]). As an example, see the literature search documentation for sensory irritation (pp. A-231–232).
- Tier 2 Suggested Revision (Recommendation 2.3): EPA should expand the text explaining the choices of the elements of the PECO statements.

EPA Response to Tier 2 Suggested Revision 2.3: As noted previously, the PECO criteria for each search were clarified and now have a consistent presentation in the assessment methods (Section 2.2 of the revised Toxicological Review), with explanations provided for many of the specific inclusion/exclusion criteria. The language used to describe specific inclusion or exclusion criteria has been standardized across health effects by study type (e.g., epidemiology studies).

##### Related Public Comments

- Public Comment (American Forest and Paper Association): “We wanted to address the Agency to the fact that two of our Formaldehyde (FA) manuscripts were not cited in the Review (Golden 2011, Golden and Holm 2017). It is important to note that these manuscripts report on critical aspects in the FA literature that have not been addressed in the Review. Including this information would supply useful perspective on the complex literature regarding the relationship between FA and asthma and sensory irritation and lead the Agency to different conclusions. EPA also does not include or discuss other publications that deserve more careful consideration. Our examination of the Review shows the following:
  ○ EPA relies on two papers to derive a Point of Departure (POD) for asthma that show no positive association with the disease
  ○ EPA failed to review and incorporate critical and relevant literature
  ○ EPA failed to discuss studies accurately and transparently
  ○ These failures have led to the lack of a proper Weight of Evidence integration using the Best Available Science
  ○ EPA is overly conservative in its use of uncertainty factors leading to ‘acceptable concentrations’ that are far below other recent regulatory evaluations of FA that use a practical Weight of Evidence approach
  ○ This conservatism has led to EPA-derived ‘acceptable’ concentrations that exist in virtually no locations on earth.”

EPA Response: Both manuscripts noted by the commenter are reviews and tagged to the project for this assessment as supplemental materials. Reviews and other documents without primary data are typically tagged as such [see IRIS Handbook; (U.S. EPA, 2022)]. Separately, regarding the first bullet in the comment, a NOAEL is an example of a POD that can be based on a study that does not show an effect for a hazard identified based on the available evidence base as a whole. The other bulleted comments are not specific to the content of the assessment and thus no response is provided. However, comments elsewhere in this Appendix that contain content specific to this assessment may include EPA responses relevant to the intent of this public comment.

- Public Comment (ToxStrategies): “U.S. EPA’s literature search and/or review of their literature search results incorrectly filtered out relevant MOA evaluations that the agency should have considered.”

EPA Response: As previously described, reviews, opinions, and other articles without primary data were tracked as supplemental materials in HERO. While such materials can help to identify relevant evidence and hypotheses, the IRIS Program develops its own MOA evaluations, consistent with EPA guidelines.

- Public Comment (Anonymous): “Attached are several recent articles and reviews which may be relevant to EPA and NASEM reviewers, including several peer-reviewed pieces published since 2000 which do not appear in the main text or appendices of the draft assessment. [Hartwig et al. 2020; Chang et al. 2021; Protano et al. 2021; Agathokleous and Calabrese 2021]” [Please see docket for details and supporting information.]

EPA Response: None of the articles above contain primary data. As previously described, studies with no primary data are considered as supplemental materials and tracked in HERO. The articles above are tagged as such in the formaldehyde HERO page.

- Public Comment (Natural Resources Defense Council): “It is unclear what EPA used for its study inclusion and exclusion criteria. For example, NIEHS comments expressed concern that EPA’s literature search was inadequately broad, and unjustifiably limited. NIEHS noted that, “the limited set of search terms is unlikely to capture all animal studies of hypersensitivity” and may exclude other important studies. Moreover, the public is unable to fully access the Systemic Evidence Maps, which are crucial to convey critical information such as how the study inclusion and exclusion criteria were applied to particular studies, and how that may limit the data set used for the evaluation. NIEHS identified this concern as “Tier 1 – Necessary Revision”, which NRDC agrees with.”

EPA Response: Please note that the systematic evidence map (SEM) used to update the literature from 2016-2021 was included in Appendix F of the external review draft, not as a separately released file. In the current assessment, the SEM has been integrated into the Assessment Methods section (Section 2.2), the Appendix documentation of literature searches (Appendix B.2), and the formaldehyde HERO page (link above). Regarding the other NIEHS comment on literature search terms, some of the animal studies of hypersensitivity were identified through the immune conditions-specific search and others were identified through a separate search focusing on mechanistic information relevant to immunological and inflammatory changes. These studies were ultimately judged by EPA as informative of mechanism for the purposes of this assessment and are discussed in detail in Appendix C.7. No “missed” studies on hypersensitivity were identified by peer-reviewers or public commenters.

- Public Comment (Troy Corporation): “…While there is an extensive section of text denoting criterion for assessment study selection it is not clear why certain studies were chosen for a particular toxicological endpoint.”
  “In addition, the assessment literature review did not capture many of the new more recent scientific studies industry has prepared since the last IRIS assessment. Since 2010, there has been a continual effort by industry and academia alike to provide additional data on key formaldehyde inhalation toxicological endpoints. This new data adds to an already extensive data set on this compound. These new studies include the reanalysis of epidemiology studies, examination of the effects of endogenous versus exogenous formaldehyde and portal of entry effects, examination of formaldehyde exposure to asthma, mode of action studies and sub-chronic animal inhalation studies. In total approximately 73 additional studies have been conducted and based on the current assessment, have not been incorporated into the current document.”

EPA Response: The criteria for inclusion and exclusion of studies and effects for each hazard synthesis are described in the Assessment Methods (Section 2.2 of the revised assessment).

Specifically, regarding the “73” studies noted by the commenter, these overlap with 76 studies submitted by the American Chemistry Council in a letter to EPA in June 2022. Of these 76 studies, 7 met the assessment PECO criteria. The 69 remaining studies contained no primary data, or were out of scope (e.g., no health-related information). Of the seven studies that meet the assessment PECO criteria, all seven were/are cited.

As previously described, reviews and studies with no primary data are considered as supplemental materials and tracked in HERO. Such studies are often not cited in IRIS assessments.

- Public Comment (United States Chamber of Commerce): “Moreover, over the last decade, more than 40 peer reviewed studies have demonstrated safe thresholds for formaldehyde, including important methodologies published in recent weeks, award-winning re-analysis of key data, and several lines of evidence demonstrating the safe use of formaldehyde for EPA regulatory purposes. For example, ‘A Review of Stable Isotope Labeling and Mass Spectrometry Methods to Distinguish Exogenous from Endogenous DNA Adducts and Improve Dose–Response Assessments’ published by the American Chemical Society in December 2021. Unfortunately, many of these high-quality studies and reviews are ignored, briefly dismissed, or misused by EPA in the draft assessment (as noted in comments filed by the Small Business Administration).”

EPA Response: EPA conducts an independent analysis of the studies meeting PECO criteria that contain primary data. Reviews and other studies with no primary data (all of the 40+ papers noted by the commenter) are considered as supplemental materials and tracked in HERO. EPA has considered in detail many of the cited supplemental studies and discussed a subset of those in the assessment, including support for the conclusion regarding lack of evidence for remote distribution of exogenous formaldehyde. The adduct data and the experiments based on the stable isotope labeling and mass spectrometry (SILMS) method alluded to above, including Lai et al., 2016; Lu et al., 2010, 2011; Moeller et al., 2011; and Yu et al., 2015, were crucial to supporting EPA’s conclusions in Section 3.1 (Toxicokinetics). EPA extensively evaluated (in Section 3.1.1 and Appendix C.1.12) the models in papers by Schroeter et al., 2014 and Campbell et al., 2020 which accounted quantitatively for the influence of endogenous formaldehyde on exogenous formaldehyde uptake. The NASEM consensus report (see section on “EPA’s use of toxicokinetic data and dosimetry models” in that report) found EPA’s evaluation and use of these models thorough and appropriate.

- Public Comment (American Chemistry Council): “There are numerous studies that should have been evaluated in the Draft Assessment, but were not cited or referenced. EPA has excluded or dismissed a number of key studies, reviews, responses, and presentations, with a majority having been presented in correspondence and presentations by the ACC Formaldehyde Panel to the Agency since 2011.”
  “Routinely over the last decade, the Panel has met with and provided IRIS staff information on new scientific findings and publications related to the deficiencies identified in the NASEM review of the 2010 Draft IRIS Assessment of Formaldehyde. It is therefore unclear why many of these studies have not been included in the 2022 Draft Assessment after such longstanding outreach and communication with EPA on the part of the Panel. A representative sample of the engagements and communications with the EPA have been provided as attachments to this submission.”
  “The 2022 Draft Assessment does not respond to NASEM’s recommendation to clearly document its methods for study selection…As noted, systematic review methods have developed substantively since the NASEM 2011 review. The IRIS Handbook includes a highly detailed and structured process for literature search and selection. However, the process for inclusion and exclusion of studies from IRIS assessments, including formaldehyde, diverges from current best practices. For example, there are numerous places in the systematic review when EPA can choose to exclude studies without justification, including after refinement of the study plan or organization of the hazard assessment.”
  “The 2022 draft Formaldehyde Review is not clear on the methods for study selection, and in some cases appears to deviate from best practices for systematic review, particularly for studies published between 2016 and 2021. Specifically, for the 2016-2021 studies, after comparing these studies to the PECO criteria, EPA assessed whether studies were “potentially impactful” - a subjective process to further narrow the body of evidence. EPA states this process relies on “expert judgment by two reviewers.” Particularly concerning is that aspects of study quality assessment are intertwined in these criteria - for example, the criteria pertaining to animal studies with multiple dose levels. While multiple doses are preferred to evaluate dose-response relationships in animal toxicity studies, some single-dose studies may still be informative for critical endpoints or MOAs and therefore should not be excluded before full evaluation. Additionally, criteria related to selecting relevant mechanistic data are vague, with no guidance other than inclusion of only those “most directly related to the mechanistic uncertainties identified in the 2017 draft.” The subjective selection of recently published studies is apparent in the failure to include numerous critical re-analyses and MOA assessments, as detailed in the comments submitted by ACC’s Formaldehyde Panel.”
  “The systematic review of literature contained in the Draft Assessment was inadequate. The Draft Assessment itself verifies that the systematic review was bifurcated and rushed, and that simple literature searches were performed pre-2017 and post-2017…The above indicates that, against EPA policy, a full systematic review of the literature was not conducted before release of the Draft Assessment for peer-review. Also, inadequate, and incomplete science cannot be justified by a desire to “expedite” an update to a 12-year-old draft document. This deficiency must be addressed before any further revisions are initiated.”
  “The criteria for inclusion/exclusion of studies published after 2017 are unclear. The Draft Assessment gives the appearance of subjectively excluding evaluation of any studies that did not impact conclusions made before 2017, in confidential internal review drafts that remain unavailable to the public and were not externally peer-reviewed.” [Please see docket for details and supporting information.]

EPA Response: Please see EPA responses above on this topic, including EPA’s response to public comments on the systematic review methods utilized in the formaldehyde assessment versus those presented in the IRIS Handbook (Approach to Documentation of Methods, above in Section F.1.3), which are also pertinent here. As previously described, the HERO database was used to document study screening decisions. And, as above, reviews and commentaries without primary data, including re-analyses of MOA assessments, are considered as supplemental information.

#### Study Evaluation (Steps 3 and 4)

##### Peer Review Findings and Comments

- Finding (6): EPA provides overall and outcome-specific evaluation criteria that are generally consistent with the common domains for risk-of-bias analysis and their application in practice. However, the criteria are found in several different locations in the documents and in some cases are inconsistently presented and integrated across the documents. As a result, the committee was challenged to reconstruct the study evaluation approach and how the criteria were applied for study evaluation.
- Finding (7): The considerations listed for classification of study confidence and evaluation of each study by at least two independent experts are adequate. However, the committee’s case studies (see Box 2-1 and Appendix C) revealed inconsistencies in how evaluation criteria were described and applied in EPA’s evaluation of human and animal studies.
- Tier 2 Suggested Revision (Recommendation 2.4): EPA should thoroughly review the Draft Assessment documents to address issues of consistency and coherence so as to ensure that its methods can be applied and replicated with fidelity. The reviews for each outcome in Chapters 4 [noncancer health effects] and 5 [cancer] provide more specific guidance.
  ○ Related committee comments (from p. 33, noting that similar comments were provided elsewhere related to laying out ‘criteria’ for confidence selection for noncancer effects): “For cancer outcomes, the risk-of-bias domains are described generally for each outcome, but there is no clear description of how judgments were made concerning the classification of studies as having high, medium, or low confidence or not being informative for each risk-of-bias domain.” … “Comparable tables for different outcomes may not have sufficiently parallel descriptions.” AND “These tables have two columns for exposure and for study design and analysis (see, e.g., Table A-33). The descriptions in the table cells sometimes mention risk-of-bias domains described elsewhere in the document. However, the documentation is not specific to each domain as a heading in the tables (because there are only two table headings rather than six for the high, medium, low, not informative classification).”
  ○ Related committee comments: “For pulmonary function, while the study evaluation criteria provided in Table A-43 appear to be appropriate, they do not overlap with the methodologic issues mentioned in the text.”
  ○ Related committee comments: “Appendix A document presents a table (Table A-43) of criteria used to categorize study confidence for epidemiological studies as high, medium, low, and not informative. This table considers two aspects: (1) exposure, and (2) study design and analysis. Neither the Main Assessment nor the Assessment Overview references Table A-43.”

EPA Response to Tier 2 Suggested Revision 2.4: Tables have been added to the assessment methods clarifying considerations for each study evaluation domain applied in the context of each health outcome (Section 2.3 of the revised Toxicological Review). The narrative text and tabular content have been reviewed for consistency and updated. The table noted above is now referenced in the assessment.

In making these criteria more explicit and rechecking their consistent application across studies, several changes were made in confidence characterizations of individual studies or of specific analyses or outcomes within studies, although none of these changes affected the evidence synthesis or integration judgments.

Changes in Sensory Irritation study evaluations:

- Alexandersson and Hedenstierna (1989) was changed from low to medium because a potential selection for healthy workers and attenuation of the measure of association was the only limitation of significance identified.
- Berglund et al. (2012) was changed from high to medium because measures to blind participants to exposure was not described and an uncommon endpoint measurement was used.

Changes in Allergy and Asthma study evaluations:

- Branco et al. (2020a) was previously classified as low confidence; this was changed to medium for the dichotomized analysis but kept at low for the continuous (per IQR). This change was made because the concern regarding the analytic strategy that did not take into account the shape of the dose-response was more pronounced for the continuous variable than for the dichotomized variable.
- Huang et al. (2017) was previously classified as low confidence; this was changed to medium for the rhinitis analysis but kept at low for the eczema and asthma analyses. This change was made based on the greater uncertainty regarding validation of truncated version of ISAAC questionnaire for the latter two outcomes compared to the former; the rhinitis questions were similar to those used in other studies, whereas the eczema and asthma questions were more limited.
- Mi et al. (2006) was changed from medium to low confidence, consistent with other studies with a limited (4 hour) exposure measurement period.
- Raaschou-Nielsen et al. (2010) was changed from low to medium confidence because EPA to be consistent with other studies in which limitations which were expected to lead to a reduced (attenuated) effect estimate.
- Li et al. (2019) and Yu et al. (2017) were previously classified as two separate low confidence studies, based primarily on reporting deficiencies in each. EPA’s re-review that the 2019 is essentially a replication of the 2017 study protocol using a later birth cohort. The missing information in each paper was found in this other paper, although the study authors did not respond to several requests from EPA for confirmation regarding the exposure measurement period and exposure levels for each study cohort. Based on this information, EPA present these as a single medium confidence study.

Changes in Nervous Systems Effects evaluations:

- The review resulted in changing the confidence conclusions for two of the studies based on the criteria for exposure assessment (Bellavia et al., 2021) (medium to low) and other limitations including small number ALS deaths (Pinkerton et al., 2013) (high to medium confidence).
- In ensuring consistency in evaluations across studies of a particular type (e.g., in vivo experimental animal studies), three in vivo studies examining mechanistic changes received a revised rating (high to medium confidence) Sorg, 2001, 626595, Tsukahara, 2006, 626805, and Hayashi, 2004, 626503

##### Related Public Comments

- Public Comment (American Chemistry Council): “The Draft Assessment often relies on animal studies performed with novel and unvalidated test methods to reach conclusions. As an example, as described further in these peer-review comments, each of the animal studies relied upon for developing organ specific reference concentrations (osRfCs) in the Draft Assessment, relied on novel methods, such as measuring seminiferous tubule diameter, without providing any hematoxylin and eosin (H&E) stained tissue section histopathological evaluation by a trained pathologist, or measuring metal concentrations in lungs or testes without even providing critical information such as body weights, food consumption, hematology, clinical signs, sufficient number of animals for statistical evaluation, etc. as is expected of any well conducted toxicology study using validated endpoints for assessing toxicity.”
  “A critically deficient evaluation domain for the assessment of formaldehyde is methanol co-exposure. Any study (epidemiological or animal) with methanol co-exposure should generally be classified as uninformative rather than “low confidence” when related to systemic effects. The Draft Assessment overstates in their conclusions “…the evidence indicates that inhalation of formaldehyde likely causes increased risk of xxx” for studies that were confounded by methanol.”
  “Epidemiology studies without any analytical sampling should have been excluded from the determination of hazard and/or dose-response…Below is an example of an epidemiology study, Taskinen et al. (1999), that was graded with medium confidence. This paper should not have been carried forward due to multiple deficiencies, including a lack of analytical data (Table 1-58, p. 1-415)”
  “The study quality assessment framework used in the 2022 draft appears different from that described in the Handbook, allows for significant reviewer subjectivity, and ultimately is unclear on how confidence classifications were determined. The depiction of EPA’s evaluation of study confidence process (see Figure II) is convoluted, and the study evaluation tables (e.g., Appendix Tables A-105 and A-106) that summarize results of individual studies are difficult to read and interpret.”
  “Further, the EPA approach to study quality assessment focuses on three areas: (1) reporting quality, (2) risk of bias, and (3) study sensitivity, but primarily emphasizes risk of bias. Certain categories are more important to judging study quality than others. For example, exposure characterization is a critical evaluation domain for epidemiological studies, including the formaldehyde literature, which is plagued by studies with poor surrogates for exposure (e.g., studies relying on next of kin reporting embalming practices of deceased workers). The 2022 draft includes a lettered “grading” system for exposure assessment; this system, which is poorly described, does not appear in the Handbook or in any other agency study evaluation framework. Additionally, risk of bias is only one facet of internal validity (bias reflects a systematic error only, while internal validity is also impacted by other non-systematic errors).”
  “Overall, EPA does not sufficiently address the NASEM recommendations relating to evaluating the quality and reliability of individual studies and must improve this in their general approach to study quality evaluation. EPA should revisit its framework for evaluating exposure assessment in epidemiological studies of formaldehyde exposure and revise its process for evaluating mechanistic information to ensure it is a uniform and reproducible methodology across endpoints. EPA should consider aligning with the exposure characterization domain within the data quality evaluation framework developed for Toxic Substances Control Act (TSCA) risk evaluations.
  “The 2022 Draft Assessment conclusions are speculative and lack scientific confidence because EPA applied a flawed and subjective study evaluation method, especially in the analysis and interpretation of the epidemiology data…While EPA has made progress in this area, the study evaluations presented in the 2022 Draft Assessment need improvement and reflect two distinct but related issues: 1) several important deficiencies remain in the evaluation framework provided in the IRIS Handbook and 2) the 2022 Draft Assessment fails to follow the IRIS Handbook.”
  “The 2022 draft incorporates a defined methodology and detailed discussions of mechanistic and MOA information for some endpoints, but not others. The Supplemental Information details a set of criteria for judging the strength of the evidence for mechanistic events associated with non-cancer respiratory effects (see Table A-64). The draft also provides evidence tables summarizing general study characteristics and findings for mechanistic studies of respiratory effects. The ‘’utility and notes’ column provides the overall confidence rating for that study; however, details on the rating are provided only for some low confidence studies.” “EPA’s analysis and interpretation of epidemiology data in the 2022 Draft Assessment is flawed. Not only does the study evaluation framework deviate from that required in the IRIS Handbook, but also EPA does not clearly communicate the results of its study evaluation. EPA also fails to consistently apply its own IRIS rating system for the robustness of exposure categorization, fails to thoroughly consider exposure latency, implements a highly subjective methodology for evaluating study reporting, biases, and sensitivity, and selectively interprets studies according to particular exposure metrics. All of these oversights lead to a lack of confidence in EPA’s conclusions. Specific issues are described in detail below.” [Please see docket for details and supporting information.]

EPA Response: Confidence classifications and the supporting rationale (emphasizing limitations that reduce confidence) are provided for approximately 1,000 individual studies in the IRIS formaldehyde assessment. The overall goal of these study evaluations was to evaluate the extent to which the study results are likely to represent a reliable, sensitive, and informative presentation of a true response. The study evaluation approach and evaluation criteria are presented in Section 2.3 of the Toxicological Review (and in the Preface of the external review draft). The study evaluation judgments for each study are documented in Appendix B.3 (and in Appendix A of the external review draft), and limitations identified in Appendix B.3 that could substantively change a result presented in the study, or the interpretation of that result, are highlighted within each respective hazard synthesis (Sections 3.2 and 3.3). Consideration of factors noted by the commentor are included in the study evaluation process, including a primary focus of EPA’s evaluation on exposure assessment (e.g., see Section 2.3.9 for methods for rating exposure in the cancer epidemiology studies, which was specifically raised by the commentor). While study evaluations have been refined for epidemiological studies in the IRIS Handbook compared to methods used in the formaldehyde assessment, the core considerations are similar. This is not surprising as the methods used in the formaldehyde assessment shaped the methods presented in the IRIS Handbook.

The NASEM committee was supportive of EPA’s study evaluation approach and even conducted case studies to evaluate consistency of how studies were considered. The committee did not have any Tier 1 recommendations on this topic. EPA has revised the document to address the committee’s findings and Tier 2 commendations (see above). EPA’s response to public comments on the systematic review methods utilized in the formaldehyde assessment versus those presented in the IRIS Handbook are discussed above (Approach to Documentation of Methods) and are also pertinent here. Please note that TSCA does not have a finalized data quality evaluation framework.

#### Evidence Synthesis (Steps 5 and 6)

##### Peer Review Findings and Comments

- Finding (8): In general, the strength-of-evidence categories are appropriate for the human and animal evidence streams and consistent with the state of practice.

##### Related Public Comments

No related public comments were submitted.

#### Evidence Integration (Step 7)

##### Peer Review Findings and Comments

- Finding (9): In general, the IRIS Program’s approach to evidence integration is appropriate and grounded in methods used by EPA and many other entities for reaching causal conclusions. Expert judgment is involved in this phase of the assessment, and the IRIS Program appears to draw on appropriate multidisciplinary groups to evaluate the evidence.
- Finding (10): The committee identified aspects of the process for further consideration and reformulation. First, the IRIS Program’s schema blurs the distinction between evidence synthesis and integration, combining them into a single step, as exemplified by the summary tables for each health outcome that include both “evidence judgment” and “hazard determination.” (e.g., Table 1-4). A clear distinction between synthesis and assessment of the overall strength of evidence would be preferable conceptually and more consistent with the state of practice. [goes on to indicate the following: “expanded [integration] narrative descriptions would be useful for documenting the rationale for the classifications made. The tables are useful but terse, as is the accompanying text… The terms used—demonstrates, indicates, suggests, or is inadequate—are aligned with the IRIS Handbook, but are not obviously hierarchical…[and] also are used inappropriately, as in the inherent proposition that it is the evidence itself that “demonstrates” or “indicates.” The use of these terms represents an unnecessary source of inconsistency with the state of practice.”]
- Tier 2 Suggested Revision (Recommendation 2.5):
  ○ [2.5 a]: The assessment should be edited to more sharply demarcate the synthesis and the integration of evidence discussions.
  ○ [2.5 b]: EPA should expand the narrative descriptions of the evidence integration step, or should follow published methodology while providing detailed explanation of any adaptations.

EPA Response to Tier 2 Suggested Revision 2.5:

EPA appreciates the NASEM committee findings on the evidence integration conclusions of “demonstrates” and “indicates” as not being clearly hierarchical. However, these phrases are used in the IRIS Handbook (U.S. EPA, 2022), which underwent Agency review, Interagency review, and public NASEM peer review in 2021. That said, the IRIS Program understands there may be potential confusion and defines these terms in the IRIS Handbook, along with descriptions of patterns of findings across evidence that lead to different evidence integration judgments. The definitions are also presented in the formaldehyde assessment (Section 2.6).

- 2.5a: In the revised assessment, synthesis judgments are more clearly drawn prior to and separately from the evidence integration judgments. Summary sections after each evidence synthesis section have been added to better demarcate the synthesis judgments and the supporting rationale. These sections also use bullets to describe factors (e.g., consistency) influencing synthesis judgments and include the synthesis judgment. In addition, corresponding edits were made to the description of the evidence synthesis and integration framework methods.
- 2.5b: In the revised assessment, the evidence integration step follows the methodology published in the IRIS Handbook, with revised documentation consistent with the application of that approach in the evidence profile tables that support each evidence integration narrative.

##### Related Public Comments

No related public comments were submitted.

#### Use of Mechanistic Evidence

##### Peer Review Findings and Comments

- Finding (11): Overall, the committee found that EPA has been thorough and transparent in identifying the scientific literature with regard to mechanistic evidence. However, the definition of “impactfulness” and how this concept was applied are not well described. Similarly, the term “other inferences” is used in the sections on integration of cancer evidence, but the term is not explained.
- Tier 2 Suggested Revision (Recommendation 2.6): To increase the transparency of the evaluation of mechanistic data, EPA should clarify key terms (e.g., “impactfulness,” “other inferences”) and their application to specific studies. “Impactfulness” can be defined (in Table F-12 and elsewhere), and “other inferences” can be explained in discussing the approach to evidence integration in the “Preface on Assessment Methods and Organization.”

EPA Response to Tier 2 Suggested Revision 2.6:

- The “other inferences” are now better defined in the assessment methods (Section 2) and the specific inferences relevant to each health effect-specific decision more clearly documented during evidence integration.
- The definition for “impactfulness” (which primarily applies to the SEM literature update) has been revised for clarity (see Section 2 of the revised Toxicological Review).

##### Related Public Comments

- Public Comment (Natural Resource Defense Council): “Regarding the assessment of the weight of evidence (i.e., evidence integration), NRDC strongly supports EPA’s reasoned approach regarding mechanistic information, stating that mechanistic events and associations are preferred, but that, “the lack of mechanistic data explaining an association did not discount results from human or animal health effect studies” (p. 38). To that end, NRDC disagrees with the comment from ATSDR, arguing that the lack of mechanistic information should be treated not as a data gap, but as a “reason to down-grade the evidence findings.” NRDC supports EPA’s determination that, “Mechanistic understanding is not a prerequisite for judging the evidence, and thus absence of knowledge should not be used as a basis for decreasing strength NTP (2015); NRC (2014a). The human relevance of animal findings is assumed unless there is sufficient evidence to the contrary [see IARC (2006); U.S. EPA (2005a)].” (p. 40) This is also consistent with the IARC Preamble, updated January 2019 following a global process of public comment and scientific peer review. EPA could update the IARC reference in the text.”

EPA Response: No response needed as comment was supportive of the assessment, which is consistent with EPA guidelines.

- Public Comment (American Chemistry Council): “For the evaluation of MOA information, EPA notes that ‘in general, studies relevant to mechanistic interpretations informing hazard identification were not individually evaluated.’ However, the sections that follow indicate that some data were assessed for risk of bias and other domains, but with differing methods for each endpoint. For non-cancer respiratory mechanistic studies, EPA follows the general Handbook framework for rating these studies as low, medium, or high confidence. For mechanistic studies of non-cancer extra-respiratory effects, such as circulating blood cells, however, it appears no confidence evaluations were conducted, despite the fact that some of these studies have been used to inform carcinogenic hazard in the LHP malignancies (see page A-554).”
  “Finally, for epidemiological studies of genotoxic endpoints, a third process was used, which is summarized as follows: ‘…an overall conclusion of “no obvious bias” was used if no concerns were identified. for studies with a potential bias identified, the potential bias or issue was summarized in the comment row. For each assay (e.g., chromosomal aberrations, CBMN, Comet assay), factors related to assay methods that could affect the endpoint values were identified using published reviews from collaborations that compared assay methods across epidemiological studies (Fenech, 2020; Moller et al., 2020; Bonassi et al., 2011; Fenech et al., 2011; Valverde and Rojas, 2009; Bonassi et al., 2005).’ Interestingly, on page A-222, the mechanistic epidemiological study by Zhang et al., (2010), which has been all but refuted in a number of peer-reviewed publications (see, for example, Gentry et al., 2013; Mundt et al., 2017) is discussed only briefly by EPA; the comment column simply states, ‘small sample numbers, no obvious bias.’ The Gentry and Mundt papers are also cited, but the re-analyses presented in these studies are largely dismissed and not integrated with Zhang et al. (2010) or any of the other human studies evaluating markers of genotoxicity.”
  “The Draft Assessment relies on multiple assumptions [regarding MOA] rather than considering alternative viewpoints supported by data in the formaldehyde literature.” “Discussion of MOA is more often speculative than grounded in empirical demonstration.” “EPA misinterprets Recio et al. (1992) to support an implausible genotoxic mode-of-action for carcinogenicity.”
  “EPA provides no criteria for its process for considering the strength of the mechanistic studies for genotoxic findings. EPA should standardize its approach to considering mechanistic and MOA studies and apply it consistently across endpoints. Mechanistic and MOA data should not be relegated to ‘supplemental information’ but more fully integrated into the assessment beginning early in the IRIS process.”
  “The 2022 Draft Assessment does not incorporate best practice recommendations from NASEM and other agencies on the evaluation and integration of MOA information…Other systematic review frameworks recommend evaluating mechanistic information and information on potential MOAs with the same level of rigor as the other lines of evidence (animal and human). WHO (2021) is particularly clear on this matter, stating: ‘Regarding mechanistic and pharmacokinetic data (two separate types of data), these are often described as being contextual or associated with sub-questions. However, if these data are anticipated to be critical in making determinations of hazard or dose– response, such data should be included in the review and subjected to the same appraisal and structured evaluation process applied for other data types (emphasis added).’…The 2022 Draft Assessment, however, does not appear to implement any of these best practices for the use of mechanistic studies and MOA information. Mechanistic studies and information supporting (or not supporting) MOA are largely relegated to “supplemental” information and considered only in the evidence integration phase in the context of their ability to inform hazard conclusions based on human and animal evidence.”
  “The 2022 Draft Assessment does include more discussion of MOAs relative to the 2010 Draft Assessment. EPA acknowledges that inhaled formaldehyde is not distributed to an appreciable extent beyond the respiratory tract to distant sites. EPA, therefore, assumes inhaled formaldehyde acts via a different pathway. Although EPA looks at endpoints that could be key events in an MOA, EPA has not proposed a biologically plausible MOA…In fact, the postulated MOA is lacking any experimental data to support EPA’s conclusion that inhaled formaldehyde that EPA acknowledges is not distributed to sites beyond the portal of entry and causes cancer.” “The 2022 Draft Assessment’s treatment of MOA and mechanistic data renders it inappropriate for regulatory use…EPA’s dismissal of the importance of MOA and mechanistic information is inconsistent with the Agency’s own approach to human health hazard assessment for a given chemical under the Toxic Substances Control Act (TSCA), one of the stated objectives for the 2022 Draft Assessment. EPA’s guidelines governing application of systematic review in TSCA risk evaluations characterizes the ‘the availability of a fully elucidated mode of action (MOA) or adverse outcome pathway (AOP)’ as ‘highly preferred.’ These guidelines argue that ‘[m]echanistic evidence may provide support for biological plausibility and help explain differences in tissue sensitivity, species, gender, life-stage or other factors,’ emphasizing that ‘EPA/OPPT plans to prioritize the evaluation of mechanistic evidence instead of evaluating all of the identified evidence upfront. This approach has the advantage of conducting a focused review of those mechanistic studies that are most relevant to the hazards under evaluation.’” [Please see docket for details and supporting information.]

EPA Response: A large part of the document (spread out over many sections of the Toxicological Review and Appendices) is devoted to bringing all the mechanistic information to bear on evaluating MOA. Section 2.3 describes the methods for evaluating the mechanistic evidence and Appendix B.3 documents the results of individual mechanistic study evaluations. Sections 2.5 and 2.6 provide the framework for EPA’s synthesis of this evidence and detail how the mechanistic evidence informs the overall evidence integration decisions, respectively.

Specifically regarding cancer MOA, Section 3.2.5 discusses the evaluation of the respiratory cancer MOA in the context of EPA’s guidelines and Section 3.3.3 outlines and evaluates the mechanistic evidence relevant to LHP cancers. Relevant to these interpretations Section 2.3.6 details the methods used to evaluate individual mechanistic studies most relevant to immune-, inflammatory-, or tissue injury-related changes, while Section 2.3.10 describes the methods used to evaluate the genotoxicity studies (the results of these evaluations are documented in Appendix B.3.6 and Appendix C.3, respectively). Also note the analyses probing the temporal- and dose-dependence of the two primary MOAs contributing to nasal cancer development in Section 3.2.5 and Appendix D.2., as discussed in other EPA responses below, and the use of nonlinear approaches (Section 5.2.1) to addressing one MOA contributing to upper respiratory tract cancers.

As noted above the NASEM committee found that “… EPA has been thorough and transparent in identifying the scientific literature with regard to mechanistic evidence.” The committee did not have any Tier 1 recommendations on this topic and EPA has revised the document to address the committee’s Tier 2 comments. It is noted that the IRIS Program’s approach, and the approach used in this assessment, for consideration of mechanistic evidence is consistent with approaches being implemented by other health agencies and EPA programs (i.e., prioritizing mechanistic evidence instead of evaluating all of the identified evidence upfront). Although some revisions have been applied to the MOA syntheses in the revised assessment, the underlying approach was not changed.

- Public Comment (United States Chamber of Commerce): “…the SBA cautioned EPA against ‘making definitive conclusions about causes based on evidence that only demonstrates association and without identifying a mode of action’ while identifying nearly a dozen key studies excluded by EPA and repeatedly warning that EPA ‘does not have a mode of action or mechanistic evidence’ supporting its core conclusions.^10^”
  “Additional interagency concerns were identified during internal review, such as the Agency for Toxic Substances and Disease Registry (ATSDR) statement that the lack of mechanistic data ‘needs to be a reason to down-grade the evidence findings. It is significant.’”

EPA Response: EPA guidelines [e.g., (U.S. EPA, 2005)] and the IRIS handbook methods (U.S. EPA, 2022) do not support downgrading confidence ratings in the evidence conclusions when there is a lack of mechanistic understanding. Further, the evidence integration approach applied in this assessment explicitly evaluates the support for causation based on application of adapted Hill considerations for causality. EPA Note: Interagency reviewer (e.g., ATSDR; SBA) comments were on a draft that was revised prior to public release. Please consult the full interagency review comments in the EPA docket.

- Public Comment (ToxStrategies): “The adoption of the KCC approach by the U.S. EPA indicates that risk assessment is, depending on one’s point of view, (d)evolving into an anti-hypothesis, anti-expert, anti-MOA approach of simply demonstrating that a chemical has certain characteristics in common with other carcinogens as opposed to understanding how a chemical causes a specific tumor. It is noteworthy that lead author on the KCC approach (Smith et al. 2016; Smith et al. 2020) is also a coauthor on epidemiological studies linking inhaled formaldehyde exposure to leukemia (Zhang et al. 2010; Zhang et al. 2009). Instead of using the KCC approach, the U.S. EPA should follow its own guidance for the risk assessment of carcinogens as described in U.S. EPA (2005).”
  “Page 1-302 states that formaldehyde has been shown to be genotoxic or mutagenic in a variety on in silico and in vitro test systems. To what is EPA referring regarding in silico test systems? A search of the Toxicological Review for the term “silico” revealed no additional hits. A search of the Supplemental Information for the term “silico” revealed one hit in a citation for Yoo & Ito (2018a). Searching for “Yoo” revealed the study in Table F-12” Mechanistic studies relating to respiratory tract cancers, focusing on genotoxicity additional hits” where the study was listed as “not impactful.” As was discussed in Thompson et al. (2020), BBDR in silico modeling suggests that formaldehyde-induced nasal tumors in rats could be predicted with little or no direct mutagenic contribution from DNA-protein crosslinks as the nasal tumors could be explained by mutations accumulating from increased regenerative cell proliferation (Conolly et al. 2003).”
  “Pertinent to the release of the US EPA’s External Review Draft of Toxicological Review of Formaldehyde(Inhalation) I was surprised to see that a 2020 review article I coauthored on the mode of action of formaldehyde-induced nasal tumors in Critical Reviews in Toxicology^1^ was not cited anywhere in the 193-page Assessment Overview, 789-page Toxicological Review, or the 1058-page Supplemental Information documents^2^. This omission by the U.S. EPA is unfortunate as there are critical data integration topics in the review article that might have informed U.S. EPA’s assessment. Moreover, Thompson et al. (2020) is an update of the mode of action (MOA) for formaldehyde-induced nasal tumors published by McGregor et al. (2006), which the U.S. EPA did cite in their assessment. As such, the omission of Thompson et al. (2020) is disappointing.”
  “Below are comments relevant to the missing Thompson et al. (2020) article (and others), additional comments relevant to the MOA evaluation for formaldehyde-induced nasal tumors, as well as separate comments related to some of the noncancer evaluation in the U.S. EPA (2022) assessment. Broadly speaking, these comments highlight the following:
  ○ Failure to integrate relevant science into the MOA for nasal tumors in rodents
  ○ Failure to response appropriately to previous review by the National Research Council
  ○ Failure to adhere to U.S. EPA MOA guidance and practices
  ○ Failure to consider nonlinear approaches for protecting against upper respiratory tract cancers
  ○ Failure to use appropriate benchmark dose modeling software and practices
  ○ Poor organization of the various assessment documents”
    [Please see docket for details and supporting information.]

EPA Response: EPA did not adopt the 10 key characteristic of carcinogens (KCCs) approach for evaluating carcinogenicity. EPA uses this as a tool to organize the available mechanistic information but relies on the EPA cancer guidelines MOA framework when conducting the analyses. The 2021 NASEM peer review report on the IRIS Handbook was supportive of using key characteristics as an organizational construct for mechanistic evidence, including for carcinogenicity. With respect to publications not cited in the assessment, please see prior EPA responses (for instance, the comment by Troy Corporation) about how reviews and studies with no primary data are considered as supplemental materials and tracked in HERO (Section 5.2.1). Please also see the specific descriptions in the Toxicological Review that describe how the relevant information was identified (Section 2) and EPA guidelines were adhered to in evaluating the respiratory cancer MOA (Section 3.2.5), as well as the consideration of nonlinear approaches to addressing one MOA contributing to upper respiratory tract cancers, including derivation of an RfC (Section 5.2.1). EPA has updated the BMDS modeling, as described in responses to NASEM and public (including from ToxStrategies) comments below, primarily in Appendix F.3.8.

#### Finding on Evidence Integration

##### Peer Review Findings and Comments

- Finding (12): Evidence integration is the critical last step in hazard identification, and transparency is essential, requiring a sufficiently comprehensive narrative documenting the decision-making process. In completing its determination of hazard identification in the 2022 Draft Assessment, EPA drew on long-standing approaches for inferring causation, including the Bradford Hill considerations, first enumerated in a 1965 publication (Hill, 1965). Nonetheless, the 2022 Draft Assessment deviates from those long-established approaches in several respects, including (1) blurring of the boundary between evidence synthesis and integration, and (2) the choice of terminology used to describe the strata in the four-level schema for classifying the strength of evidence. Additionally, in some instances the narratives concerning the evidence integration step are too terse to explain fully why EPA came to its confidence conclusions.

EPA Response to Finding 12: As previously described above under “Evidence Integration (Step 7)”, the assessment has been revised to clearly demarcate evidence synthesis judgments from evidence integration and to more clearly document the different factors that influenced the evidence integration confidence conclusions for each health effect. Regarding the evidence integration framework, the committee seemingly mistakenly interpreted the 5-level evidence integration schema applied in the external review draft as 4 levels because the category of ‘not likely’ was only mentioned as a footnote (since it wasn’t used for this evidence base). However, in the revised assessment, the 5^th^ evidence synthesis category of “compelling evidence of no effect” and the 5^th^ evidence integration category of “strong evidence supports no effect” are now described in the Assessment Methods (see Section 2 of the revised Toxicological Review), although these categories do not apply to any of the hazard synthesis for this assessment. Regarding the terminology used, as noted above, the IRIS Program understands there may be potential confusion and defines the terms used for evidence integration in the IRIS Handbook, along with descriptions of patterns of findings across evidence that lead to different evidence integration judgements. These definitions are also presented in the assessment (Section 2.6).

##### Related Public Comments

No related public comments were submitted.

#### Dose-Response Assessment (Step 8)

##### Peer Review Findings and Comments

- Finding (13): The committee found EPA’s considerations for study inclusion to be reasonable, although the discussion of those considerations in multiple places in the documents made it more difficult to determine what the considerations were and how they were applied.
- Finding (14): Although EPA provides criteria for study inclusion in the dose-response assessment, it does not include any discussion of how these criteria were applied to the specific studies chosen for dose-response. Using the Hanrahan et al. (1984) study as a test case, there are inconsistencies between the characteristics of the study and EPA’s criteria for studies that would be selected for dose-response analysis.

EPA Response to Findings 13 and 14: More specific criteria for study selection for dose-response analysis are now laid out in methods (Section 2.7 of the revised Toxicological Review) and documentation has been added for each health effect and study in the dose-response section (see Section 5). Specifically, in response to Finding (14), Sections 5.1 and 5.2 of the Toxicological Review now also includes tables and expanded discussions of the rationale for selecting and advancing studies for noncancer and cancer dose-response analysis and, ultimately, for selecting the RfC and IUR. This includes a specific rationale for each medium or high confidence study supporting why it was or was not advanced for POD derivation. Given the expanded study selection documentation now provided, the initial section on dose-response analysis is now presented as two separate sections: study/endpoint selection and POD derivation.

EPA has reviewed the Hanrahan et al. (1984) study and the Liu et al. (1991) study for selection for dose-response analysis and, as outlined in Section 5, decided not to advance either individually. Rather, they were advanced together as complementary studies and advanced the combined dose-response data to draw strength from each other (which helps to mitigate several limitations specific to one of the studies but not the other), in keeping with the example provided in the NASEM peer review report.

- Tier 2 Suggested Revision (Recommendation 2.7): EPA should consider using information from studies that are complementary to each other to derive benchmark concentrations for outcomes of interest (see also Appendix D [point of departure analysis using two studies: a case study]). For example, multiple studies can be complementary by widening the exposure scale, broadening the age groups, and including vulnerable or susceptible groups.

EPA Response to Tier 2 Suggested Revision 2.7: As noted above, EPA provides additional analyses on sensory irritation building from the recommendation above in the revised assessment (see Appendix D.1.1 of the revised assessment, which builds from methods described in Appendix D of the NASEM 2023 report) by combining the dose-response data from Hanrahan et al. (1984) and Liu et al. (1991). Using the data available and building on approaches outlined by the NASEM committee, EPA now estimates a BMCL from the combination of these studies. Although concerns about the precision of the estimate remains, which impacts confidence in the derived toxicity value (see related comments below), the derived POD is considered much more stable and appropriate as compared to the BMCL based on Hanrahan et al. (1984) alone.

- Tier 2 Suggested Revision (Recommendation 2.8): Given that EPA has requested additional information from some study authors, the authors of the Liu et al. (1991) study could be approached for additional information that would help EPA reconstruct an overall dose-response graph (see also Appendix D [examples of issues identified by the committee]).

EPA Response to Tier 2 Suggested Revision 2.8: EPA has not been able to locate a working email address for KS Liu and has found no recent publications. EPA contacted a study co-author, Dr. Ken Sexton, at two email addresses found on publications seeking any additional information on the dose-response modeling; however, both attempts were not delivered. Note that EPA also contacted Dr. Krzyzanowski regarding additional information on the regression modeling details from Table 5 of that study and received a response.

Although EPA was unable to acquire additional information in relation to the study by Liu et al. (1991), additional modeling efforts related to this study were successful, expanding on the committee’s efforts on this topic presented in Appendix D of the NASEM report (see Appendix D.1).

##### Related Public Comments

- Public Comment (American Chemistry Council): “NASEM has provided several recommendations regarding the development of toxicity values, including that toxicity values should be more representative of the body of evidence, and should use formal methods for combining multiple studies. It is critical that EPA address NASEM recommendations regarding developing toxicity values to better reflect the state-of-the-science in this field and demonstrate how the systematic review process informs the development of the values.”
  “Subjective exclusion of “evidence against” (not supporting) the conclusions reached in the Draft Assessment is contradictory to EPA guidelines…The Draft Assessment, however, sets aside both animal and mechanistic information and solely calculates Reference Concentrations (RfCs) and Inhalation Unit Risks (IURs) based on individual study results. Toxicokinetic, dosimetry, animal, and mechanistic data are not integrated into the assessment of epidemiology results when calculating exposure limits/IURs, when they appear to contradict numerically identified associations from epidemiology.” [Please see docket for details and supporting information.]

EPA Response: Note that the draft RfC in the external review draft was based on multiple studies and health effects, consistent with prior NRC (2011) recommendations. And, while a single epidemiology study was used to estimate the draft IUR due to limitations in the evidence base, toxicokinetic, dosimetric, and mechanistic modeling approaches were applied to the animal data to derive complementary unit risk estimates based on the animal cancer data. These decisions in line with prior recommendations are retained in the revised assessment. In addition, as noted above, EPA followed NASEM’s recommendation to jointly model the dose-response from the two complementary studies of formaldehyde exposure in mobile homes and sensory irritation.

### F.1.4 Other Public Comments on Assessment Methods and Organization

- Public Comment (American Chemistry Council): “Ensuring and maximizing the quality of the 2022 Draft Assessment requires the application of ‘a “weight-of-evidence” approach that considers all relevant information and its quality […].’ Equally important, the substance of the information must be ‘accurate, reliable and unbiased,’ which entails the use of ‘the best available science and supporting studies conducted in accordance with sound and objective scientific practices […].’ EPA must ensure that the information presented in the 2022 Draft Assessment ‘is comprehensive, informative, and understandable.’
  “Due to a deficient systematic review, information that was, or should have been, known to the Administrator was excluded from the Draft Assessment.”
  “The 2022 Draft Assessment does not fully incorporate NASEM (2011) systematic review recommendations or current best practices for implementing systematic review in chemical toxicity assessments.”
  “The 2022 Draft Assessment does not follow guidance in the IRIS Handbook. The 2022 Draft Assessment makes no specific reference to the IRIS Handbook with the exception of a single footnote. However, some of the general processes mirror, at least in part, the IRIS Handbook. In other parts, it deviates from the IRIS Handbook more substantively. There are several places in the 2022 Draft Assessment with language and tables that are borrowed from the IRIS Handbook, but, in some cases, subtle changes were made that, while easily missed, are not unsubstantial.”
  “The 2022 Draft Assessment does not consider IRIS Handbook recommendations regarding MOA.”
  “The frequent and inconsistent use of subjective terms, results in an overly complicated Draft Assessment that is confusing and difficult to interpret. As shown in Table 1, the term “low concentration” can range from about 0.002 to 0.4 mg/m^3^, “high concentration” from about 3 to >12 mg/m^3^, and “excessive concentrations from about 7 to ≥20 mg/m^3^, the overlapping and ill-defined subjective terms makes interpretation of statements such as those highlighted in Table 2 almost impossible to put into context. The level of subjectivity in the language used in the Draft Assessment must be reduced to increase transparency in study interpretations.” “There are many instances of language supporting a subjectively predetermined outcome.” “The Draft Assessment frequently combines “statistics not reported” with “not statistically significant” and undefined “significant” determinations. The basis for statistical and biological relevance as treatment-related is not transparent.”
  [Please see docket for details and supporting information.]

EPA Response: The NASEM peer review panel supported EPA’s weight-of-evidence conclusions for all included health effects. As a reminder, the IRIS Program sought feedback from the NAS on the evolving IRIS systematic review methods in 2014 and 2018 and, in 2020–2022, the completed draft IRIS Handbook (U.S. EPA, 2022) received public comment and peer review by NASEM^44^. The systematic review methods developed and applied in the external draft of the IRIS formaldehyde assessment (2021) to make it responsive to the NAS (2011) report served as the basis for many of the methods in the IRIS Handbook (and thus the methods are consistent). It is separately noted that NAS (2011) indicated EPA should not wait until systematic review is fully implemented to produce IRIS assessments. However, as previously described, several aspects of the approaches in the draft assessment have been adjusted in the revised assessment to be more consistent with current practices in systematic review. Regarding terms usage, it is acknowledged that there can be differences in descriptions such as ‘high’ and ‘low’ exposure, which often differs depending on the context of the studies being described (e.g., sets of residential human studies on one outcome versus experimental animal studies on another); attempts were made to ensure inclusion of the specific exposure context rather than these terms alone. Regarding statistical significance, which is not the only consideration in synthesis decisions, the assessment is consistent with descriptions in the IRIS Handbook.

- Public Comment (United States Chamber of Commerce): “… we strongly encourage EPA to revise the 2022 draft IRIS assessment and incorporate the best available science and practices for systematic review. A formaldehyde IRIS assessment that does not consider the weight of scientific evidence could lead to unwarranted regulations that would ripple through the supply chain.”

EPA Response: The assessment has been revised based on the consensus comments from the NASEM peer review panel and other specific public comments, including recommendations that improve the clarity of the methods applied to the assessment (e.g., the weight of evidence, or evidence integration, approach and documentation). However, the scientific conclusions in the external draft were supported by the NASEM panel and these conclusions, while more transparent and better supported, are fundamentally unchanged in the revised assessment.

- Public Comment (ToxStrategies): “Overall, the document is difficult to follow as pertinent information is scattered amongst three separate documents: an Assessment Overview, a Toxicological Review, and Supplemental Information. This reviewer found it difficult to follow the assessment whether reading printed hard copies or a computer screen. In some places there are lengthy passages without any supporting references, making it difficult for the reader to know which studies the U.S. EPA is using to support a given statement, even for readers familiar with the formaldehyde literature. As written, topics are covered in differing degrees of depth in multiple places. Perhaps an alternative approach would be to have combined the Assessment Overview and Toxicological Review into two or three separate documents with as minimal overlap as possible. Possible alternatives include portal of entry (POE) vs systemic effects or cancer vs non-cancer effects—perhaps with dose-response analysis in a separate document altogether. The current approach needs serious reconsideration.”

EPA response: See the EPA Response to Tier 1 Recommended Revision 2.1.

- Public Comment (Troy page 1): “It was difficult to assess and understand EPA’s conclusions for many of the toxicological endpoints identified in the assessment and this was compounded by the incorporation of the draft IRIS Handbook recommendations and additional explanation on the process for the determination of the acceptability of studies. EPA’s approach towards endpoint selection is inconsistent and confusing since it is not clear if they followed the recommendations in the draft IRIS handbook or chose another approach.”

EPA Response: The assessment follows the IRIS Handbook approach (U.S. EPA, 2022). The presentation of the methods have been clarified to increase transparency in response to the peer review Tier 1 Recommended Revision 2.1 (above). This includes increased clarity regarding endpoint and study selection methods in Section 2 of the revised assessment.

## F.2 NASEM REPORT CHAPTER 3: TOXICOKINETICS; CHARGE QUESTION 2: TOXICOKINETICS

### F.2.1 Charge Question and Peer Review Comment Summary

#### Charge Question 2: Toxicokinetics

Several assumptions and interpretations were applied in the Toxicological Review that were based on current research (although the draft acknowledges that uncertainties remain). Please answer parts (a), (b), and (c) considering the extent to which the available science on the toxicokinetics of inhaled formaldehyde is clearly presented and appropriately applied in the assessment of potential respiratory and systemic (i.e., nonrespiratory) health hazards.

a. Please comment on the Toxicological Review conclusion that inhaled formaldehyde is not likely to be distributed in appreciable amounts beyond the respiratory tract to distal tissues. This conclusion underpins the organization of the assessment and several key assumptions.
b. Please comment on the Toxicological Review assumptions (based on [a]) that:
  - Inhaled formaldehyde is not directly interacting with tissues distal to the portal-of-entry (POE) to elicit systemic effects.
  - Formaldehyde levels in the blood or at systemic sites are not appreciably changed as a result of formaldehyde from exogenous sources (inhalation).
  - Inhaled formaldehyde does not cause appreciable changes in normal metabolic processes associated with formaldehyde in distal tissues. Therefore, studies examining potential associations between levels of formaldehyde or formaldehyde byproducts in tissues distal to the POE (e.g., formate in blood or urine; brain formaldehyde levels) and health outcomes are not considered relevant to interpreting the human health hazards of inhaled formaldehyde.
c. Please comment on the Toxicological Review evaluation of considerations regarding endogenous formaldehyde in assessing the health risk due to inhaled formaldehyde.

#### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 6 Consensus Panel Findings (numbered below; one Finding has multiple parts)

### F.2.2 Distribution of Inhaled Formaldehyde; Metabolism, Binding, and Removal of Inhaled Formaldehyde

#### Peer Review Findings and Comments

- Finding (1): EPA concluded that inhaled formaldehyde is not distributed to an appreciable extent beyond the respiratory tract to systemic sites; thus, inhaled formaldehyde is not directly interacting with tissues distal to the portal of entry to elicit effects. EPA’s conclusions regarding systemic delivery of inhaled formaldehyde are based on its expert judgment, with the support of available scientific evidence.
- Finding (2): Despite the lack of evidence regarding systemic delivery of formaldehyde to distant sites, the biological basis for observed systemic effects (described in Chapters 4 and 5) remains unclear. Additional research is needed to address this apparent discrepancy.

#### Related Public Comments

- Public Comment (United States Chamber of Commerce): “ATSDR also stated that EPA’s assumptions regarding the toxicokinetics of formaldehyde exposure used to develop systemic reference concentrations ‘…doesn’t make any sense’ and that EPA should examine confounding toxicities ‘before making any evidence conclusion for formaldehyde.’”
- Public Comment (American Chemistry Council): “Since the NAS (2011 review), numerous studies have conclusively demonstrated that inhaled formaldehyde is not systemically circulated through the blood or other systems. Furthermore, there is now direct molecular dosimetry evidence that, at concentrations below 15 ppm, there is no detectable systemic delivery of inhaled formaldehyde, at detection limits over a thousand times lower than endogenous levels of formaldehyde. The Draft Assessment, however, fails to take this evidence into account and incorporate the recommendations of the NAS (2011) peer-review by developing RfCs for reproductive and developmental effects (Table 2-10) that rely on the assumption of systemic delivery of inhaled formaldehyde.”
  “Over the last four decades, toxicokinetic and toxicodynamic studies have consistently demonstrated a lack of systemic distribution of inhaled formaldehyde concentrations up to 15-20 ppm when directly measured in tissues (Heck et al., 1985; Casanova et al., 1988). More recent publications quantified protein and DNA biomarkers of formaldehyde exposure confirming that there is no systemic distribution of formaldehyde air concentrations ≤15 ppm (Lu et al. 2010, 2011; Edrissi et al. 2013, 2017; Yu et al. 2015; Lai et al. 2016; Leng et al. 2019).” “Data from multiple sources provide strong evidence that formaldehyde is not systemically distributed and, therefore, could not directly cause any systemic effect. The Draft Assessment assumes that formaldehyde acts via an unknown pathway to elicit systemic effects (e.g., female reproductive or developmental toxicity, male reproductive toxicity, nervous system toxicity, and leukemia).” [Please see docket for details and supporting information.]

EPA Response (to both public comments above): The assessment conclusions regarding systemic effects are based on an assumption of a lack of distribution of inhaled formaldehyde to systemic sites, a toxicokinetic conclusion supported by the peer reviewers. This includes concluding that exogenous formaldehyde is not systemically distributed to remote tissues; that inhaled formaldehyde does not directly interact with cells in the bone marrow is not likely; and that in vitro studies of direct administration of formaldehyde to cells from distal tissues are not informative to the assessment. However, a lack of understanding of how inhaled formaldehyde can cause systemic effects without systemic distribution is insufficient to outweigh the formaldehyde-specific evidence that those effects are happening. EPA Note: Interagency reviewer (e.g., ATSDR) comments were on a draft that was revised prior to public release. Please consult the full interagency review comments in the EPA docket.

### F.2.3 EPA’s use of Toxicokinetic Data and Dosimetry Models

[Please note that this section includes multiple comments relevant to cancer dose-response modeling.]

#### Peer Review Findings and Comments

- Finding (3): The committee found that EPA used toxicokinetic data as follows:
  ○ [a] EPA used these data to support its assumption that “inhaled formaldehyde is not distributed to an appreciable extent beyond the respiratory tract to systemic sites.” Thus, EPA assumed that inhaled formaldehyde does not directly interact with tissues distal to the portal of entry to elicit effects. EPA’s conclusions regarding systemic delivery of inhaled formaldehyde are based on its expert judgment, with the support of the available scientific evidence.
  ○ [b] EPA concluded that studies examining potential associations between levels of formaldehyde or formaldehyde by-products (e.g., formate) measured in distal tissues and health outcomes were not relevant to inhaled formaldehyde. This conclusion is consistent with EPA’s state-of-practice methods and supported by the available scientific evidence.
  ○ [c] EPA concluded that formaldehyde toxicokinetics show significant route-to-route difference (e.g., inhalation versus oral). With few exceptions (e.g., genotoxicity), EPA focused solely on inhalation studies. The committee supports this decision and found it to be consistent with EPA’s state-of-practice methods.
  ○ [d] EPA used toxicokinetic data as a primary consideration informing causality during its evidence synthesis step, as “an explanation for any observed differences in responses across route of exposure, other aspects of exposure, species, or life stages.” Toxicokinetic data were used to examine consistency across studies and to evaluate biological gradient/dose-response data. Overall, the committee found that the portions of the 2022 Draft Assessment describing the toxicokinetics of formaldehyde and associated computational models are well organized and extensive. The 2022 Draft Assessment accurately reflects current understanding of the toxicokinetics of inhaled formaldehyde. The literature review in the 2022 Draft Assessment appears to be up to date and includes relevant studies published as of the assessment’s release date. The use of these data in the synthesis step is consistent with EPA’s state-of-practice methods.
- Finding (4): The use of these models [dosimetry, CFD models, including use in deriving cRfC for respiratory pathology] is appropriate and consistent with EPA’s state-of-practice methods.
- Tier 2 Suggested Revision (Recommendation 3.1): To enhance transparency, the summary tables (e.g., Tables 24, 43, and 44) should explicitly identify the models used to derive flux values. Table 44 should clearly indicate whether the BBDR models used here are equivalent to Models 1 and 2 identified in Table 43 and the text. Table 46 should indicate which flux model was used.

EPA Response to Tier 2 Suggested Revision 3.1: The model used for flux is added in the main text and also added as a footnote where appropriate (i.e., the application of the dosimetry model is now summarized in Sections 5.1.2 [e.g., Footnote 49] and 5.2.1 [e.g., Table 5-37] of the revised Toxicological Review, with the detailed evaluation and discussion presented in Appendix C.1.12). The values in “Table 2-23” (Table 5-38 in the revised Toxicological Review) are not from EPA models (1 & 2) but as derived by Conolly et al (2004) based on their models. This is now clarified in the revised text. Table 5-38 compares risk estimates predicted by the human extrapolation models in Conolly et al (2004) with those derived by EPA from the NCI occupational epidemiology data.

- Finding (5): The 2022 Draft Assessment generally provides a thorough discussion of the strengths and weaknesses of the available models, including an extensive discussion of how EPA used them in the assessment.
- Tier 2 Suggested Revision (Recommendation 3.2): To increase transparency, EPA should provide additional clarification regarding its decision not to use the BBDR model to extrapolate rat nasal carcinogenicity to humans. Criteria used by EPA to determine whether the models would be adequately robust for this purpose are not readily available in the 2022 Draft Assessment. Likewise, EPA should provide additional support for its decision not to use the BBDR model (Conolly et al., 2004) for this extrapolation because of its conclusion that formaldehyde-induced mutagenicity, modeled as proportional to DPC concentration, is not relevant to formaldehyde’s carcinogenicity.

EPA Response to Tier 2 Suggested Revision 3.2: There are two separate recommendations in the above. First, regarding model predictions, EPA’s evaluation of model robustness considered established criteria on model specification, calibration and prediction. These criteria have been added to the sub-section on “Extrapolation using a biologically based dose-response model” in Section 5.2.1.

The second comment pertains to the inferences from the model results in Conolly et al (2003, 2004) [i.e. “it’s conclusion” = “model’s conclusion”]. EPA’s decision to not use the BBDR modeling for extrapolation was on account of instabilities in model predictions, and not on account of the inference in Conolly et al. (2004) regarding formaldehyde-induced mutagenicity as not relevant to its carcinogenicity. Therefore, the underlined text in the paragraph below from the draft 2022 Toxicological Review is now deleted to improve the clarity of this paragraph. The underlined deleted text does, however, relate to a major uncertainty that is discussed in Section 5.2.1 and Appendix D.2.2. Also see the response to the public comment by TERA.

“A clonal expansion model (Conolly et al., 2004), as well as possible variations of this model, developed for extrapolation of the rat nasal cancer risk to human exposure scenarios are carefully evaluated. Predictions using these models for humans are found to be not robust at any exposure concentration. [underlined: Furthermore, a key model inference in Conolly et al. (2003), (Conolly et al., 2004) that formaldehyde-induced mutagenicity, modeled as proportional to DPX concentration, is not relevant to its carcinogenicity is found to be extremely uncertain.] Accordingly, the clonal expansion modeling of the rat data is employed to derive multiple PODs and corresponding HECs but it is not used for extrapolating to human exposure scenarios.”

- Finding (6): Documentation of the dosimetry methods used is variable in the 2022 Draft Assessment, especially with regard to some summary tables (for example, Table 2-27). Discussion of the comparison of and basis for unit risk estimates for nasopharyngeal cancer in humans and nasal squamous cell carcinomas in rats mentions the use of CFD and PBPK models without identifying the specific models that were used.
- Tier 2 Suggested Revision 3.3: To increase transparency, EPA should address these shortcomings by updating tables and text to better document its dosimetry methods.

EPA Response to Tier 2 Suggested Revision 3.3: Citation of the relevant models have been added, as described above.

#### Related Public Comments

- Public Comment (University of North Carolina at Chapel Hill): “The IRIS Draft did not recognize the importance of development of chemical-specific biomarker of formaldehyde exposure/molecular dosimetry data in its evidence-based risk assessment…Due to the absence of data for formaldehyde-specific biomarkers, the EPA IRIS Draft could not unambiguously assess the differential contribution of formaldehyde when cofounding factors, such as methanol co-exposure, when present…How could the IRIS draft conduct rigorous evidence-based risk formaldehyde assessment using only data based on non-formaldehyde specific approaches that do not involve formaldehyde-specific biomarkers and could not provide accurately measure the contribution of exogenous formaldehyde under the substantial endogenous background of formaldehyde?” “Recommendations: The EPA IRIS Draft needs to discuss the limitations of available data/methodologies, highlight the significance of SILMS-generated formaldehyde-specific biomarker data, and integrate dosimetry data provided by the rich formaldehyde-specific biomarker data into risk estimates of formaldehyde.”
  “The IRIS Draft misunderstood or underestimated the significance and utility of stable isotope labeling and mass spectrometry methods in understanding the potential for formaldehyde carcinogenicity and its use in characterizing dose-response in quantitative risk assessment…The ability to distinguish DNA damage caused by exogenous formaldehyde from substantial background endogenous formaldehyde-induced lesions is crucial. Accurate molecular dosimetry of both endogenous and inhaled formaldehyde is essential for science-based risk assessment of formaldehyde exposure.” “Recommendation: The EPA IRIS Draft needs to discuss the utilities and advantage of SILMS and, thus, to use the rich datasets we generated over the last decade to improve evidence-based risk assessment of formaldehyde.”
  “The IRIS Draft did not appreciate and interpret key data on the kinetics studies of formaldehyde-induced DNA adducts… The EPA IRIS Draft noticed the results of the time-course exposure study by stating ‘rat nasal N2-hmdG adduct formation was also positively associated with exposure duration, with adducts accumulating to levels >/=5 times higher after 28 days of exposure to 2.5 mg/m^3^ compared to single exposures.’ However, the IRIS Draft did not provide any discussion on the repair/loss and half-life of formaldehyde-induced DNA adducts, which is quite surprising as information on the fate and repair/loss kinetics is essential to assess mutagenicity and carcinogenicity of a genotoxicant like formaldehyde.” “Recommendation: The IRIS Draft needs to be revised to discuss the kinetics data on formaldehyde-induced DNA adducts, half-life and the steady state of exogenous DNA adducts to more accurately characterize mutagenicity and genotoxicity of formaldehyde in an evidence-based risk assessment.” [Please see docket for additional details and supporting information.]

EPA Response: The adduct data and the experiments alluded to were crucial to supporting EPA’s conclusions in Section 3.1 (Toxicokinetics). EPA concluded that exogenous formaldehyde is not systemically distributed to remote tissues; that it is likely that inhaled formaldehyde does not directly interact with cells in the bone marrow; and that in vitro studies of direct administration of formaldehyde to cells from distal tissues are not informative to the assessment.

With regard to dose-response modeling, the experimental data provided by the internal biomarkers measured in these studies were used by Starr and Swenberg (2016) in attempts to bound human cancer risks. These estimates were carefully evaluated by EPA, concluding that the method does not necessarily provide an upper bound on the slope of the dose-response at low exogenous exposures (see Section 5.2.5). The analyses supporting the conclusion that this “bottom up” approach does not provide a reasonable upper bound are described in Appendix D.2.4. In addition, Section 3.1 reviews and discusses the large uncertainties associated with these attempted bounding estimates (e.g., high variability in endogenous formaldehyde levels; model-based predictions that any external exposure causes some increase over background levels).

It is separately noted that the dose-response modeling conducted by EPA evaluates risk that is additive to background (which includes responses that may be attributed to the effects of endogenous exposure) due to inhaled or exogenous exposure concentrations. EPA carried out a sensitivity analysis based on the revised dosimetry in Schroeter et al., and found that the use of this model does not appreciably alter the BMD modeling results (i.e. the POD used for linear extrapolation in estimating the nasal cancer unit risk). This is explained in Section 5.2.1. Overall, as noted in the NASEM Finding (5), the assessment “…provides a thorough discussion of the strengths and weaknesses of the available models, including an extensive discussion of how EPA used them in the assessment.”

- Public Comment (Thomas B. Starr): “…All of EPA’s and Crump et al.’s (2014) claims regarding the ‘bottom-up’ approach are no more than speculative ‘hand-waving’. In what follows, we address and rebut these claims regarding our approach with formaldehyde-specific data.” [Please see docket for details and supporting information.]
- Public Comment (University of North Carolina at Chapel Hill): “The EPA IRIS Draft used speculations, instead of any data, to decline the adoption of the bottom-up approach that offers the opportunity to serve as an independent ‘reality check’ on low-dose risk estimates. The EPA IRIS Draft concluded that ‘the bottom-up approach does not necessarily provide an upper bound on the slope of the dose-response at low exogenous exposures, primarily because the ratio of background tumor incidence to internal endogenous concentration at the true target tissue may underpredict the slope of the dose-response above that endogenous concentration.’ The EPA IRIS Draft further stated that ‘This is further discussed in Crump et al. (2014)’ yet without providing any data to support such a claim in the Draft. In fact, Crump et al hypothesized in the Letter to the Editor that ‘A sublinear dose–response relationship over the endogenous range is clearly plausible on biological grounds. For example, it is likely that baseline levels of DNA repair enzymes and other protective systems evolved to deal with endogenous DNA damage would work most effectively for lower levels of endogenous adducts.’ (Crump et al. 2014) Once again, no data were provided to support such a hypothesis in either Crump et al. 2014 or the EPA IRIS Draft. Without development of data to the contrary, the approach taken by Swenberg et al. remains fully supported by existing data and is not questioned by unfounded hypotheses.” “Recommendation: The EPA IRIS Draft must be revised to provide specific evidence, instead of speculations, for decision-making in terms of the utility of the bottom-up approach in low-dose risk estimates.”

EPA Response (to both public comments above): NASEM’s peer review did not indicate a concern with EPA’s position on the “bottom- up” approach. The commenter’s 2013 and 2016 papers suffer from the same fundamental flaw mentioned in Section 5.2.5, such that results from their bottom-up bounding approach cannot be considered plausible upper bounds. The multiple reasons for this conclusion are detailed in Appendix D.2.4. In making this determination, EPA is not necessarily assuming a concave upward dose-response over the endogenous range but identifying a plausible scenario under which the dose-response curve pertaining to endogenous formaldehyde could take this shape. EPA demonstrated that the bottom-up approach would not give an upper bound in this case. Appendix D.2.4 also identifies other concerns with the calculations in the “bottom up” approach. In view of NPCs being rare cancers, EPA also carried out a bounding calculation as a reality check and demonstrated that the unit risk estimate derived for NPC incidence is not implausible in comparison to actual case numbers (see Section 5.2.1).

- Public Comment (Toxicology Excellence for Risk Assessment): “EPA should follow its own guidelines and develop a low dose cancer extrapolation based on a dual MOA. The proposed hockey-stick approach of EPA’s own award winning scientist, Rory Conolly, would likely approximate the end result, but other approaches might be considered, such as that suggested by Dourson et al. (2008) for acrylamide, or published by McGregor et al. (2006) or by Thompson et al. (2020) for formaldehyde, the latter effort which was adopted by the European Union. See in particular Table 6 and Figure 8 of Thompson et al. (2020).” [Please see docket for details and supporting information.]

EPA Response: EPA extensively explored the use of the dual MOA models developed by Dr. Conolly and colleagues, as well as alternative model structures based on the authors’ overall approach. EPA calculations were reviewed by the NASEM committee which found them “… highly responsive to the recommendations of the 2011 NRC committee regarding the use of CFD and BBDR models and modeling of time-to-tumor and time-to-death data.” In regard to the relative contributions of the dual MOAs, the modeling effort in Conolly et al. (2003) inferred that the tumorigenicity of formaldehyde in Fisher 344 (F344) rats could be explained on the basis of cytotoxicity-driven regenerative cell proliferation alone, without any contribution from a direct formaldehyde-induced mutagenic component. However, Conolly et al. (2003, 2004) did not examine the uncertainties in this conclusion and did not recognize that alternatives indicated by these uncertainties could profoundly impact low dose human extrapolation. Subramaniam et al. (2007) evaluated this inference in Conolly et al. (2003) by examining the contribution of the mutagenic component in their model as a percentage of the predicted probability of tumor--see Table IV of Subramaniam et al. (2007). The model actually attributes formaldehyde’s mutagenic potential to be responsible for 58%–74% of the added tumor probability in the range of exposures where tumors were observed (6.0 ppm – 15.0 ppm). In the low dose region, this fraction varies between 2% and 80% depending on the characterization of the dose-response curve for cell replication. Namely, the predicted probability was dependent on whether a J-shape or hockey-stick shape is assumed for the dose response for cell proliferation.

Overall, the available evidence does not support a conclusion that cytotoxicity-driven regenerative cell proliferation is the sole driver of formaldehyde-induced carcinogenicity, nor do the data support that a significant contribution of mutagenicity at lower doses is unlikely.

The extensive EPA analyses of the nasal cancer MOA evidence resulted in the selection of a linear low-dose extrapolation in calculations of nasal cancer unit risk estimates (Section 5.2).

- Public Comment (American Chemistry Council): “EPA’s approach to the evaluation of BBDR modeling in the 2022 Draft Assessment was misguided and inconsistent with EPA’s own cancer guidelines… Dr. Conolly concludes that EPA should consider the uncertainties of the BBDR model relative to the hidden uncertainties embedded in the empirical dose-response functions that they prefer, since lack of explicit description of mechanism does not avoid accountability for the mechanism, especially when so much relevant data are available… Results from [Starr and Swenberg’s] evaluation are important in bounding the potential risks for cancer in consideration of the endogenous production of formaldehyde.” [Please see docket for details and supporting information.]

EPA Response: EPA’s Cancer Guidelines prefer the use of a biologically based dose response (BBDR) model but require that such models [as well as models derived by empirical curve fits alone] need to be robust. The BBDR model referred to by this commenter was found to be numerically unstable on multiple accounts (Section 5.2.1 of the revised Toxicological Review and Appendix D.2.2); thus, it was not possible to bound human risk at any exposure concentration using this model. Extremely sensitive parameters in the BBDR modeling were also determined by fitting model predictions to the observed tumor incidence in the animal bioassay. Thus, as discussed in Crump et al. (2010), extrapolation using the BBDR model not only did not eliminate the uncertainties encountered in empirical modeling but introduced significant new sources of uncertainty. Please see EPA response above to the comment by UNC, Chapel Hill regarding the model developed by Starr and Swenberg.

- Public Comment (Ramboll): “The overall formaldehyde dataset for F344 rat nasal tumors and related mechanistic information is probably the most extensive such dataset in existence for any chemical. Given that the USEPA’s own Guidelines for Carcinogen Risk Assessment (USEPA 2005) clearly state a default preference for data-driven risk assessment, its multi-decade effort to develop a cancer risk assessment for formaldehyde, and its own significant resources in computational toxicology and risk assessment, it is curious that USEPA has not developed a BBDR model for formaldehyde. USEPA IRIS has, however, devoted considerable resources (Crump et al. 2008; Subramaniam et al. 2007; Subramaniam et al. 2008) to evaluate the CIIT BBDR model (Conolly et al. 2003; Conolly et al. 2004). Those of us who have developed biologically motivated models in support of risk assessment understand that no model is perfect, and that model analysis and iterative refinement support reductions in model uncertainty. It would have been interesting and informative, and consistent with their own Cancer Guidelines, if USEPA IRIS had chosen to use their analyses to develop a refined version of the CIIT model. Instead, USEPA has rejected the CIIT BBDR model and turned to more empirical approaches. In making this choice, USEPA is effectively saying that relevant mechanistic data are confusing and increase rather the decrease uncertainty, a position that is inconsistent with the 2005 guidelines. In this regard, it is worth noting that I [Dr. Rory Conolly] was employed in USEPA/ORD from 2005 through my retirement in February 2000 but was not consulted by IRIS on their evaluation of the CIIT BBDR model.”

EPA Response: EPA devoted considerable resources to explore fully utilizing the CIIT BBDR model for extrapolation by developing better input parameters as well as alternative BBDR model structures to those in the Conolly et al. (2003, 2004) effort. EPA’s efforts drew from the same mechanistic data utilized by these authors. These are indicated in the Toxicological Review (Section 5.2.1) and further detailed in Appendix D.2.2, as described above. EPA’s improvements over the CIIT effort covered all facets of the modeling including (a) an improved likelihood function that differentiated between whether a death occurred without a tumor or with an incidental tumor or with a fatal tumor; (b) a revised PBPK model for formaldehyde DPX that improved upon the original model developed by Conolly et al. (2000); (c) improved representation of the cell labeling data that allowed characterization of the temporal and regional variation in the dose-response for cell replication rates; and (d) alternative model structures for the division and death rates for initiated cells. However, 2-stage clonal growth models for formaldehyde based upon these different modifications all suffered from similar numerical instabilities (Appendix D.2.2). EPA’s efforts are consistent with its Cancer Guidelines that prefer the use of a biologically based dose response (BBDR) model but require that such models need to be robust.

Dr. Conolly’s assertions are incorrect. EPA consulted with Dr. Conolly on multiple occasions. First, EPA organized a three-day expert consultation in 2004 that included Drs. Rory Conolly, Julia Kimbell, Fred Miller, Linda Hanna, Chris Portier, George Lucier, and Kenny Crump. A summary of this consultative meeting and a separate report by Dr. Conolly were provided in Appendix H of the 2010 peer review draft report. The recommendations of this panel provided the basis for EPA’s evaluation of the CIIT modeling in the current Toxicological Review. Subsequently, Dr. Conolly was an internal reviewer on Subramaniam et al. (2007), Subramaniam et al. (2008), and Crump et al. (2008), and the authors provided EPA management a detailed disposition of Dr. Conolly’s comments prior to internal clearance of the manuscripts. Furthermore Dr. Conolly commented on EPA’s analyses of the BBDR models in the peer-reviewed literature. All these peer-reviewed publications, including exchanges in the form of letters to the editor, were completed prior to EPA’s 2010 draft assessment.

- Public Comment (Ramboll, continued): “A full examination of the uncertainties associated with empirical modeling of dose-response, side-by-side with the uncertainties that USEPA has identified in the CIIT BBDR modeling, would be informative. For example, one could ask about the relative uncertainty of dosimetry based on CFD modeling in anatomically realistic models of rat and human nasal passages versus empirical modeling of dose- response that does not specifically address dosimetry at all. Ignoring dosimetry does not, and should not, remove concern for the role of dosimetry as a determinant of dose-response. Uncertainty about dosimetry exists for any model of toxicant/carcinogen dose-response. Is a dose-response analysis that explicitly describes dosimetry inherently more uncertain than an approach that wholly ignores dosimetry? This same argument, comparing data-driven and empirical descriptions, can be applied to each of the main components of the BBDR model. Empirical models effectively hide explicit uncertainties about the shapes of the dose-response curve because the empirical models do not acknowledge the mechanistic determinants of dose- the other hand, explicitly describes these determinants. This situation is reminiscent of the early days of PBPK modeling (1980’s-1990’s) where PBPK models were sometimes said to increase uncertainty in the characterization of pharmacokinetics relative to empirical PK models. The need here, both for PBPK models and for the BBDR modeling for formaldehyde, is to step back and ask what determines the behavior of interest and to then realize that only relevant data and its inclusion into the dose-response analysis can address these uncertainties. BBDR modeling is simply a tool for integrating data on the mechanistic determinants of dose-response to provide a capability for predicting the entire dose-time response surface.”

EPA Response: EPA agrees that the BBDR modeling allowed for integrating a vast amount of mechanistic information used in conjunction with the tumor incidence data. EPA used the BBDR modeling of the rat data to determine the point of departure (POD) for the low dose extrapolation, and a POD was chosen at a benchmark response of 0.005 extra risk—a lower level than what would have been traditionally possible with the tumor data—because the dose-response was informed by precursor data in the form of increased cell replication as characterized by labeling index measurements. However, for reasons discussed in response to a previous public comment above by the ACC, the BBDR model did not eliminate the uncertainties encountered in empirical modeling but, in addition, introduced significant new sources of uncertainty. On other aspects of this comment, please see EPA responses above (e.g., to the public comment by the ACC).

Public Comment (Ramboll, continued):

“Issue 3- Labelling index data: … Notwithstanding the variability in the data, a clear J-shape is apparent [figure B-18 in Appendices], with an initial decrease in labeling with increasing flux to a nadir in the labeling index slightly below a flux of 2,000 pmol/(mm²- hr). At higher flux values, which are associated with cytolethal effects of inhaled formaldehyde, the labeling index increases, reflecting regenerative cellular proliferation subsequent to cell killing. Heck and Casanova (1999) suggested that DNA-protein crosslinks (DPX) due to inhaled formaldehyde act as physical blocks to the progression of the replication complex along the DNA strand, and thereby effectively reduced the rate of cell replication…The theory proposed by Heck and Casanova (1999) is supported in more recent literature (e.g. Nakamura and Nakamura 2020)…

The J-shaped dose-response for labeling index has significant implications for formaldehyde risk assessment. In the CIIT BBDR model, formaldehyde exerts a low dose linear directly mutagenic effect as a function of the formation of DPX and, simultaneously, the J-shaped dose-response for the rate of cell division. The human version of the CIIT BBDR model (Conolly et al. 2004) predicted a J-shaped dose-response for tumor risk, with risk only increasing above background at about 2 ppm inhaled formaldehyde. This result was, of course, dramatically different from USEPA’s assessments, which identify inhalation unit risks in the range of a few ppb. In this context, USEPA makes much of the variability in the labeling index data (see Time variability of labeling data, Appendices, p. B-54). The variability is used to justify alternate dose-responses that do not include the J-shape, including dose- responses that are monotonically increasing in cell division rate as a function of flux/inhaled ppm (e.g. Figures B-24 & B-25, Appendices, p. B-63). These alternative dose-responses can dramatically change the risks predicted by the BBDR model. Given the size and consistency of the Monticello et al. (1991, 1996) dataset, these alternative dose-response exercises are less than convincing… I suggest that USEPA should provide a clearly stated justification for use of cell replication dose-responses that are not J-shaped. If the size and quality of the labeling index data described by Monticello et al. (1991, 1996) is not to be trusted, then what is?

… I agree that calculation of division rates as a function of both time (age of rat) and flux is preferable. In fact, this two-dimensional approach is being used in an ongoing update of the BBDR model that is not otherwise considered here. However, USEPA is using this and similar criticisms of the CIIT BBDR modeling of the labeling index data to justify use of alternative, much more empirical dose-response models that do not capture our understanding of the biological processes involved. As noted above, the one-dimensional expression for division rate as a function of flux retains the main qualitative feature of the labeling index dataset, its statistically significant J-shape. Does USEPA really think that an empirical dose-response function that completely ignores the CIIT bioassay labeling index dataset provides greater certainty in the prediction of human risk?”

EPA response: EPA did include the J-shaped characterization of the dose-response for cell division in several models used to examine the impact of the variability and uncertainty in cell replication rates. See Figure 5-8 and Table 5-40 of the Toxicological Review as well as Figures D-29, D-30, D-32, D-33 and D-35 in Appendix D.2.2 for EPA’s consideration of J-shaped characterization of dose-response for cell division rate. All the BBDR-based dose-response curves evaluated in Appendix D.2.2 provide equally good fits to the observed tumor incidence data (i.e. fidelity to the sensitive calibration of the model is retained in these analyses). EPA’s effort characterized the considerable temporal and regional variability in the labeling index measurements unlike the approach in Conolly et al. (2003) where a time-weighted averaging of the labeling index measurements was carried out over regions that received vastly different levels of flux. The J- shape of the cell replication dose-response had no bearing on EPA’s disposition of the human BBDR extrapolation model which was numerically unstable regardless of the shape (the assessment demonstrates this for both the J- and hockey-stick shapes) (Section 5.2.1 and Appendix D.2.2).

Public Comment (Ramboll, continued):

“Labeling index data for bioassay exposure durations from 1 day through 6 weeks (Monticello et al. 1991) were measured by injecting BrdU while subsequent time points (Monticello et al. 1996) used osmotic minipumps implanted for 3 days. Calculation of a division rate constant, which is needed as an input to the clonal growth model, from labeling index data, requires an estimate of the length of the interval over which tissue is exposed to the labeling agent. Since this estimation is problematical for injection studies, the injection data were first transformed to equivalent minipump data using a factor of 6.83, which was the ratio of minipump labeling index to injection labeling index for all the control data. This factor was calculated from a total of 40 data points, 20 from pulse labeling and 20 from pump labeling. Conolly et al. (2003) then used a formula for the conversion of labeling index data into division rate constants due to Moolgavkar and Luebeck (1992). USEPA correctly note that that pulse label data should not be used with this formula. However, they apparently fail to understand that the pulse label data were transformed into equivalent pump data before they were used for calculation of division rate constants (see Maintext p. 2-71 and Appendices, p. B-54, Uncertainty due to combining pulse and continuous labeled data). Thus, the USEPA statements that the use of the Moolgavkar and Luebeck (1992) formula is “extremely uncertain” (Maintext, p. 2-71, line 26) and “problematic” (Appendices, p. B-54, line 17) and is itself problematical.”

EPA Response: EPA disagrees and has added further explanatory text to the revised Appendix (now D.2.2). It is important to understand the biological conditions under which Moolgavkar and Luebeck (1992) is applicable. Moolgavkar and Luebeck (1992) caution against applying their formula to pulse labeled data because, as indicated in their paper, it is unclear as to how long the (pulsed) label is available in the tissue. The reason this is a critical issue is that it takes about 4–8 hours of labeling for the relation between labeling index and the rate of cell proliferation to stabilize (see for example the data in Novak and Fedoroff (1996)). Therefore, one should be concerned that a 2-hour episode of pulse labeling will tend to represent the pool of cells currently in S-phase rather than inform the rate of recruitment into that pool. Consequently, it is not evident that adjustment by a multiplier can produce a reasonably correct estimate of labeling index and cell division rate for the pulse-label data of Monticello et al. (1991) that is comparable to those from the continuous-label data of Monticello et al. (1996), especially not for purposes of combining and jointly analyzing the resulting estimates of cell proliferation rates.

Public Comment (Ramboll, continued):

“Issue 6- Use of historical controls: …When the CIIT BBDR model was developed, we worked with 13 control tumors and did not anticipate the possibility of there being no control tumors. Is it reasonable to use this issue to justify rejection of the CIIT model? USEPA describes numerous alternative versions of the CIIT model in the IRIS Main text and Appendices and in the supporting publications (Crump et al. 2008; Subramaniam et al. 2007; Subramaniam et al. 2008). Thus, the ability within USEPA to develop alternative versions of the BBDR is not a constraint. Is there a reasonable alternative for scale-up of the CIIT rat BBDR model to the human version that USEPA could have implemented?…

The ratio of human to rat basal mutation rates described above and used in Conolly et al. (2004) is a means of accounting for Peto’s paradox in the scale-up of the BBDR model from the rat to human. While that approach cannot be used when there are no control tumors, alternative methods of scaling are available. For example:

○ [1] Set up a two-stage clonal growth (MVK) model for the rat nose as in Conolly et al. (2003).
○ [2] Without specifying exposure to formaldehyde or any other chemical, adjust pmutr to produce a small lifetime tumor incidence, say 10-6. Repeat with increasing values of pmutr until lifetime tumor incidence is 100%. This exercise will need to draw on relevant literature for biologically reasonable values of the growth advantage for intermediate cells (cells with one mutation) relative to normal cells (e.g. Conolly and Kimbell 1994).
○ [3] Set up the MVK model for the human respiratory tract as in Conolly et al. (2004).
○ [4] As in 2 above, adjust pmuth to obtain end of life tumor risks from 10-6 to 1.0 (100%).
○ [5] The ratio of pmuth to pmutr at given levels of lifetime risk will describe rat to human scaling of the MVK model. The values of pmuth will be several orders of magnitude smaller than the corresponding values of pmutr.
○ [6] This scaling would then be used with the human BBDR model to evaluate cancer risks associated with exposure to formaldehyde. For example, the calculated scaling factor(s) would be used to adjust the value of KMUrat, which defines the relationship between DPX and pmutr, to obtain KMUhuman.”

EPA Response: Two points may be noted. First, EPA did use the rat BBDR model to derive a POD for determining a unit risk based on nasal cancers in the rat. Because the model used precursor data, this POD was derived below the range of the observed tumor incidence (Table 5-37, Section 5.2.1). Second, as described in Section 5.2.1, the human BBDR extrapolation model was found to be numerically unstable on two accounts: (1) in the rat to human scaling of the parameter associated with formaldehyde’s mutational action, and (2) in the extreme sensitivity of minor perturbations on the assumed kinetics of initiated cells. The approach proposed above by the commenter purports to address only the instability that arises from scaling the parameter associated with formaldehyde’s mutational action. Exploration of the proposed alternative method of scaling represents future research possibilities on other chemicals. Importantly, EPA’s approach to use the human cancer unit risk estimate for the IUR was supported by the external peer reviewers.

Public Comment (Ramboll, continued):

“Issue 7- Initiated cells: … USEPA (see Maintext, p. 2-73, Kinetics of initiated cells) and Crump et al. (2008) perturb the values of these optimized parameters, particularly the I cell division rate, and show that BBDR model predictions of tumor incidence changes quite dramatically. This is, however, expected behavior when the optimized value of a sensitive parameter is arbitrarily changed…. USEPA appears to not understand that the richness of the datasets for N cells and SCC highly constrains the kinetics of I cells, and specifically the value of the I cell division rate constant. It is just plain wrong to say that there are no relevant data for I cells.” [Please see docket for details and supporting information.]

EPA Response: In some cases where clonal growth models have been successfully applied, quantitative information relevant to initiated cells are available in the form of preneoplastic foci. No such data are known for the case at hand. EPA however applied the same constraints as Conolly et al. (2003), namely that initiated cells ought to have only a very small growth advantage over normal cells and the criterion that the fit to the rat tumor incidence data is not statistically degraded in any modifications carried out for sensitivity analyses or for developing alternative model structures. The commenter also confuses the distinction between model calibration and prediction in regards considerations for sensitivity analysis. Sensitivity analysis of model predictions is now a required component of assessing model robustness; please see the section in the revised Toxicological Review on “extrapolation using a biologically based model.” (Section 5.2.1). The constraints used in these analyses are described in Section 5.2.1 and elaborated further in Appendix D.2.2. The results from alternative versions of the CIIT BBDR modeling of the rat data are presented. However, the CIIT human BBDR model developed for extrapolation of the rat model was demonstrated to be numerically unstable and could not be easily refined. The revised assessment compares the estimate derived from the CIIT model with the risk at the point of departure derived from the human epidemiology data in Section 5.2.1.

Other Public Comments on Toxicokinetics

- Public Comment (ToxStrategies): “U.S. EPA failed to respond to the spirit of the NRC’s comments on U.S. EPA’s 2010 draft formaldehyde assessment as it relates to toxicokinetics and MOA analysis.” [Please see docket for details and supporting information.]

EPA Response: Please see the 2023 NASEM consensus peer review findings on responsiveness to the NRC (2011) review above. The NASEM panel concluded that EPA was sufficiently responsive to the 2011 NRC comments on the 2010 draft formaldehyde assessment.

- Public Comment (Natural Resource Defense Council): “EPA’s presentation of the toxicokinetics – including the considerations of endogenous formaldehyde – is generally well-reasoned and well-presented.”

EPA Response: No response necessary.

- Public Comment (American Chemistry Council): “First, exogenous and endogenous formaldehyde are not similar -- they are identical. Claiming that there are no specific data indicating that they are different implies a conclusion that is not correct. While there are no data indicating that they are different, there is overwhelming evidence that formaldehyde is simply formaldehyde, regardless of where it is found or how it is generated. Secondly, stating that “the rate of cellular detoxification of exogenous formaldehyde remains unknown” ignores the wealth of data on the half-life of formaldehyde in vivo and its non-specific binding to electrophilic centers, as well as an abundance of data on the kinetics of detoxification by glutathione and aldehyde dehydrogenase. Thirdly, one of the best characterized metabolic pathways is the one-carbon pathway that includes detoxification of formaldehyde by formaldehyde dehydrogenase (ADH5/GSNOR). Stating that “our understanding the contribution of endogenous formaldehyde is minimal” ignores the extensive database demonstrating that formaldehyde is an essential anabolic building block needed for normal metabolism. Simply, one cannot live in the absence of formaldehyde. Ignoring the essentiality of formaldehyde and the equivalence of formaldehyde regardless of its origin is a fundamental flaw of the Draft Assessment. When in a state of homeostasis, there is no added risk. As such, assessing added risk in the context of homeostasis must be a critical component of the Draft Assessment and must not be put aside. Key to understanding and managing exogenous inhaled formaldehyde is that at concentrations that do not upset normal variability (i.e., ≤1-2 ppm) in metabolic processes, there is no added risk. The Draft Assessment must be revised to integrate relative dosimetry and define concentrations at which inhaled formaldehyde does not upset normal homeostasis. This topic was also the focus of the “bottom up” approach published by Drs. Swenberg, Starr and Lu in several peer-reviewed publications, which were incorrectly characterized in the Draft Assessment.”
  “The Draft Assessment concludes that an understanding of homeostasis is not important when considering if there is added risk from exogenous exposure to formaldehyde. However, it is critical to understand the normal role of formaldehyde in the body, such as its central role in one carbon metabolism when determining adversity. The Draft Assessment also speculates that inhaled formaldehyde is somehow different than endogenously produced formaldehyde, an assumption that challenges our basic understanding of chemistry. Formaldehyde is a simple molecule; it is simply formaldehyde and should not be assessed differently or separately, depending on whether it is generated in the body or derived from an external source.” “While the previous assessment and the current assessment provide a discussion of formaldehyde toxicokinetics, the 2022 Draft Assessment does not provide a discussion or consideration of when exogenous formaldehyde exposure appreciably alters normal endogenous formaldehyde concentrations, as recommended by NASEM.^79^ This evaluation is critical in drawing conclusions regarding the potential for health effects following inhalation exposure of formaldehyde…Formaldehyde is a classic example of a chemical for which the beneficial and adverse effects can only be considered in the context of dose-dependent transitions. Endogenous formaldehyde is essential to life while high exogenous concentrations result in adverse effects. There are numerous studies that provide evidence that exogenous formaldehyde does not move past the portal of entry in multiple species (i.e., rats and non-human primates) following both acute and subchronic inhalation exposure across a range of air concentrations (0.001 ppm to 15 ppm) Kleinnijenhuis et al. 201382; Lu et al. 201083, Lu et al. 201184; Edrissi et al. 201385; Moeller et al. 201186; Lai et al. 201687; Yu et al. 201588; Leng et al. 201989)… Despite decades of research using highly sensitive methods, EPA continues to derive a risk for myeloid leukemia in the absence of even a hypothesized MOA and with clear toxicokinetic evidence that formaldehyde does not move beyond the portal of entry.”
  “It is clear that toxicokinetic considerations are key to integrating the multiple streams of evidence necessary to make a sound data-driven conclusion. However, for leukemia, the Draft Assessment disregarded the wealth of information available that demonstrates that inhaled formaldehyde is not systemically distributed as well as dosimetry related to the naturally occurring background tissue concentrations of formaldehyde. Instead, the Draft Assessment relied on pure speculation to support what was apparently a pre-determined outcome. Notably, there is not one place in the Draft Assessment where the evidence against there being a mechanism of LHP carcinogenesis following inhalation exposure to formaldehyde is objectively discussed.” [Please see docket for details and supporting information.]

EPA Response: The IRIS assessment conclusions are consistent with the comment that “inhaled formaldehyde is not distributed to an appreciable extent beyond the respiratory tract to systemic sites; thus, inhaled formaldehyde is not directly interacting with tissues distal to the portal of entry to elicit effects.” The assessment likewise agrees that there is no experimentally supported, hypothesized MOA for formaldehyde induced-leukemia (Section 4.3). However, the EPA conclusions are consistent with EPA’s cancer guidelines (U.S. EPA, 2005) that lack of understanding of MOA does not provide grounds for discounting the observed epidemiologic data, which was considered robust. The document is in agreement with most of the scientific statements made by the commenter. However, EPA disagrees with certain perspectives on endogenous formaldehyde. As discussed in Section 2.7, “… the role of endogenously generated formaldehyde in human diseases is largely unknown… The focus … is to estimate the risk over background that results from only the exogenous exposure, … incidence of cancer or other health hazards that may potentially be attributed to endogenous formaldehyde is already accounted for in the background cancer incidence. Endogenous formaldehyde might be responsible for some portion of background risks for some health outcomes, particularly when normal detoxification pathways are deficient (e.g., (Pontel et al., 2015)); but that possibility is not the purpose of this review.”

## F.3 NASEM REPORT CHAPTER 4: NONCANCER HEALTH EFFECTS; CHARGE QUESTION 3: RESPIRATORY SYSTEM (PORTAL-OF-ENTRY) HEALTH EFFECTS, CHARGE QUESTION 4: SYSTEMIC HEALTH EFFECTS, AND CHARGE QUESTION 5: NONCANCER RFC

### F.3.1 Charge Questions on Noncancer Health Effects and the Noncancer RfC

This section discusses comments related to Charge Question 3 (Sections F.3.2 to F.3.5 of these responses), Charge Question 4 (Sections F.3.6 and F.3.7 of these responses), and Charge Question 5 (Section F.3.8 of these response).

#### Charge Question 3. Respiratory System Health Effects (Noncancer)

For each noncancer POE health effect considered in the assessment and outlined in (a) to (e), below (Note: descriptions of 3a to 3e are detailed within each health effect-specific section below), please comment on whether the evidence integration decisions for hazard identification are clearly described and scientifically justified (considering the extent to which the available data have been appropriately synthesized to describe the strengths and limitations). In addition, please separately comment on whether the dose-response decisions are transparent and scientifically justified, including study selection for dose-response analyses; point of departure (POD) estimates, including modeling choices and assumptions, and dosimetric adjustments; selection of uncertainty factors and derivation of candidate values; selection of organ- or system-specific RfCs (osRfCs); and confidence in the calculated values. For these well-studied health effects, confidence was consistently judged as either medium or high.

#### Charge Question 4. Systemic (i.e., nonrespiratory) Health Effects (Noncancer)

For each noncancer systemic health effect considered in the assessment and outlined in (a) to (c), below (Note: descriptions of 4a to 4c are detailed within each health effect-specific section below), please comment on whether the evidence integration decisions for hazard identification are clearly described and scientifically justified (considering the extent to which the available data have been appropriately synthesized to describe the strengths and limitations). In addition, please separately comment on whether the dose-response decisions are transparent and scientifically justified, including study selection for dose-response analyses; POD estimates, including modeling choices and assumptions, and dosimetric adjustments; selection of uncertainty factors and derivation of candidate values; selection of osRfCs; and confidence in the calculated values. Confidence was consistently lower for these effects as compared with POE effects.

#### Charge Question 5. Noncancer RfC

See Section F.3.8 for the description of the charge question.

### F.3.2 Sensory Irritation

#### Charge Question and Peer Review Comment Summary

##### Charge Question 3a. Sensory Irritation

■ The assessment concludes that the evidence demonstrates that inhalation of formaldehyde causes increased sensory irritation in humans, given appropriate exposure circumstances.^45^ Well-conducted studies in humans and animals support this hazard conclusion, and strong mechanistic evidence provides a plausible mode of action (MOA) for the identified outcome.
■ A POD from Hanrahan et al. (1984), a human study, was ultimately selected to calculate an osRfC of 0.009 mg/m^3^ for eye irritation. A composite uncertainty factor (UF_C_) of 10 was applied to address intraspecies uncertainty (UF_H_). The assessment also considers PODs from controlled human exposure studies and discusses their utility for developing an RfC for lifetime exposure as well as their potential increased utility for purposes outside the scope of the current assessment (e.g., derivation of an acute RfC).

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 5 Tier 2 Suggested Revisions
- 1 Tier 3 Future Consideration
- 10 Consensus Panel Findings (numbered below)

#### Literature Identification

##### Peer Review Findings and Comments

- Tier 2 Suggested Revision (Recommendation 4.1): To maximize transparency and facilitate replication, EPA should clarify the Medical Subject Headings (MeSH) terms used, list and justify any MeSH terms that were excluded (e.g., eye, ear, nose, or skin), provide the list of national and international reviews and assessments used to identify additional references, and provide more specific links to the Health & Environmental Research Online (HERO) database where the screening decisions are documented (see Appendix A, Section A-232, line 4).
  ○ Related text from Appendix E: “For sensory irritation, it is unclear if other MeSH terms like eye, ear, nose, or skin were used in the search because they were not reported in Table A-31. The number of studies (38 observational and 20 controlled trials) included in the 2022 Draft Assessment, as presented in Figure A-22, does not match the number of studies presented in Tables A-34 (13 residential studies), A-35 (1 school study), and A-36 (21 controlled trials). Neither of the numbers match with Tables 1-1 (14 controlled trials) and 1-2 (6 residential studies) in the Main Assessment.”
  ○ Related committee text: “EPA used four databases, and curated reference lists in published reviews and other national or international health assessments of formaldehyde (see Appendix A, Section A-231), although the flow diagram shows that only two databases were used (Figures A-22 and A-263).”

EPA Response to Tier 2 Suggested Revision 4.1: The following revisions were made in response to this recommendation:

- The specific search terms (and MeSH terms, where applicable) were and are documented in the Supplemental Materials (i.e., Appendix B.2 in the revised assessment). No MeSH terms were excluded for sensory irritation; however, PECO criteria were used to screen studies. As described in the assessment methods section, all search strings were submitted as keyword searches, which in the case of PubMed includes MeSH terms by default, except as specified with tags like [majr] which limited the search to only when the term (and any selected subheadings) are indexed as a major topic heading (not all MeSH terms). Only the terms for “formaldehyde” were tagged with [majr]. In addition, as described in the assessment methods, additional references were identified from the 2010 draft Toxicological Review and from the reference lists in the identified journal articles.
- The rationale for use of certain PECO criteria has been expanded in the methods section of the revised assessment (see Section 2.2). A footnote has been added to the PECO table for sensory irritation to specify exclusion of dermal effects.
- The revised assessment has been corrected to reflect the two databases searched for sensory irritation (not four).
- As noted in Section 2.2, for sensory irritation, the only assessment used to search for missed studies was the prior 2010 public comment draft developed by the IRIS Program. This is noted in the description of search strategies in the assessment methods section
- Studies deemed not informative and thus not extracted or discussed in the evidence synthesis are now listed in the introduction to each health effect-specific section. This was not done for mechanistic study evaluations given the larger numbers of such studies and the linked discussions of overlapping mechanistic evidence across the different health effect sections. The mechanistic studies identified as not informative are documented in Appendix B.
- The number of sensory irritation studies identified in the literature flow diagram corresponds to the number of studies in the study evaluation tables (although there was one correction made, see below) and the main toxicological review. Specifically, 58 total sensory irritation studies met the PECO criteria prior to the SEM update, including 38 observational studies and 20 controlled exposure studies (the literature flow diagram in the 2022 draft indicated 38 observational and 20 controlled exposure studies). One citation, a description of formaldehyde concentrations, was included within a cell with the PECO reference, but has now been included in the exposure column. The SEM update identified an additional five references the supplemental appendices; one was possibly impactful but was already incorporated based on previous searches. The 20 unique HERO IDs for the identified controlled exposure studies are evaluated and documented in the 17 rows of the controlled exposure table representing the different experiments. Likewise, the evaluation of the 38 unique observational studies is documented in the following in tables for residential studies, school studies, anatomy course studies (this table was not counted in NASEM review), and occupational studies (it appears this table was not counted in the NASEM review).
  Separately, for all health effects, the numbers of studies in the literature flow diagrams and the study evaluation tables do not match the number of studies in the main assessment text or tables because studies classified as not informative in the study evaluations (documented in the Appendices) were not discussed in the Toxicological review in the 2022 draft. However, for transparency in the revised draft, the studies identified as not informative are now noted in the introduction to each health effect section (which also aligns better with more recent EPA-IRIS methods).

- Finding (1): EPA excluded outdoor exposure studies (Table A-32) without providing adequate justification [see report for expanded discussion].
- Tier 2 Suggested Revision (Recommendation 4.2): EPA should include the body of evidence from outdoor exposure studies at the preliminary stage to derive a more holistic and objective assessment of the scientific literature.
  ○ Additional comments related to this topic: “…found unconvincing EPA’s argument that studies with lower exposure levels may have a limited ability to detect associations between formaldehyde exposure and health effects.” “The committee notes further that the assertion that outdoor levels of formaldehyde are universally below 0.005 mg/m3 may not correctly represent true population exposures…” See TABLE 4-2 Formaldehyde Levels in Outdoor Air Reported in Selected Studies.”

EPA Response to Tier 2 Suggested Revision 4.2: The revised assessment clarifies this rationale to highlight that this decision was not only about low exposure levels but also that the exposure measurements in these studies were poor surrogates for individual-level health effects (see Section 2.2.1). For example, the eight studies tagged as excluded because of outdoor exposure in the formaldehyde HERO page all rely on stationary sensors from which individuals assessed for health effects reside some distance from (typically within several miles). These sensors are generally only collecting data for a short period of time and involve collection of multiple pollutants (several studies do attempt to consider this source of confounding). On top of that uncertainty, ambient levels of formaldehyde in outdoor air are significantly lower than those measured in the indoor air of workplaces or residences, and the exposure range was narrow in many epidemiological studies of ambient exposure (<0.005 mg/m^3^), limiting their sensitivity to find any associations with health outcomes even if they existed. Temporal (seasonal and diurnal) and spatial variation in formaldehyde concentration is strongly influenced by photochemical interactions and traffic emissions. Consequently, the potential for exposure misclassification for estimates of individual exposure using mean formaldehyde concentrations from central outside monitors is greater than from indoor formaldehyde measurements. Therefore, the few studies examining health effects in relation to outdoor formaldehyde concentrations remain excluded in the revised assessment.

- Finding (2): In the Main Assessment (see Figure 2-3), the box representing typical formaldehyde levels depicts a sharp delineation between lower outdoor and higher indoor levels. In real-world exposure scenarios, that is unlikely to be the case; rather, a continuum of concentrations with overlapping outdoor and indoor levels is a more likely scenario (see Table 4-2 [of study report]). Figure 2-3 could show representative ranges of outdoor and indoor formaldehyde concentrations levels more accurately (see Appendix E).

EPA Response to Finding 2: The range of outdoor and indoor formaldehyde levels depicted in the figure (in Section 5.1 of the revised assessment) have been removed from the figure. In revising the assessment, it was decided that including such information in the figure is inappropriate, since IRIS assessments do not include an exposure assessment. For context on the RfC and study-specific PODs, a footnote describes one estimate of formaldehyde levels in outdoor and indoor air, and recommends the reader consult authoritative sources on exposure assessment.

##### Related Public Comments

No related public comments were submitted.

#### Study Evaluation

##### Peer Review Findings and Comments

- Finding (3): The outcome-specific criteria EPA used to evaluate the human studies were generally appropriate but the application of the specified criteria across studies appears inconsistent and it is not clear if the same set of quality criteria was applied uniformly across studies. The potential for selection bias is addressed for each of the studies. Determining the potential for selection bias in a study is challenging as the specific selection fractions that lead to potential bias are generally unknown. Cross-sectional studies are generally at risk for selection bias. The potential for selection bias may also be signaled by a low response rate and non-representativeness of a study population on exposure and outcome frequency. The committee could not find a consistent approach in how EPA evaluated the potential for selection bias, for example, across the range of observed response rates.
  ○ Additional comments related to this topic: “[The] committee found some inconsistencies between the presented human sensory irritation outcome– specific evaluation criteria and how they were applied to the Hanrahan et al. study, as well as how study limitations were presented for other sensory irritation studies…”
  ○ Additional comments on this topic: “descriptions include some of the quality characteristics listed in Appendix A.5.1 and in the text of A.5.2, but not others. For example, none of the criteria in the Selection Bias domain (recruitment, selection into study, participation independent of exposure) are included in Table A-33. …, such as the use of a validated data collection instrument, which is included in the high and medium descriptions, but not those for low. … [and] sample size is introduced as a study quality characteristic, but without discussion to inform when the sample size would be considered “large,” “small,” or “may be a limitation.”

EPA Response to Finding 3: The tables describing the outcome-specific criteria for sensory irritation (and all of the other health effect categories) were revised to include criteria for all of the evaluation domains including population selection, exposure assessment, outcome ascertainment, confounding, etc (see Section 2.3 of the revised Toxicological Review). Criteria are described for domain ratings of good, adequate and deficient. For example, for the outcome domain, a rating of “deficient” is assigned if the data collection instrument was not described and there is uncertainty whether symptoms were reported without knowledge of exposure status and concern with regard to a bias toward an overestimate of risk. For the analysis /other domain, while a specific number of participants is not given, a “deficient” rating is assigned if the sample size was small enough to result in an increased potential for unreliable results. Occupational studies with a cross-sectional design and potential for a healthy worker survival bias are considered to be adequate or good for population selection because the bias is toward the null hypothesis and would not be a concern if health risks were observed. However, the bias is noted for that domain. The application of the criteria to individual studies, including the Hanrahan et al. study, was reviewed to ensure that the evaluations included each of the domains, any limitations were noted and were consistently applied across studies. Table cells for domains considered “deficient” are shaded to highlight that the limitation is expected to result in bias or results that are unreliable.

The review of the study evaluations resulted in changing the confidence for some studies. For sensory irritation, confidence in (Alexandersson and Hedenstierna, 1989) was changed from low to medium and confidence in (Berglund et al., 2012) was changed from high to medium.

- Finding (4): The 2022 Draft Assessment described specific aspects of exposure assessment that EPA considered when evaluating individual studies, such as having a measurement protocol, duration of exposure measurement period, number of samples obtained, consideration of temperature and humidity, and percentage of measurements below the limit of detection (Appendix A, Section A-236). The text does not clarify whether systematic or random contributors to inaccuracy were assessed in evaluating information bias in individual studies, nor does it describe how the assessment took account of multiple sources of information bias.

EPA Response to Finding 4: EPA developed evaluation criteria that assessed whether any identified information bias had the potential to attenuate the measurement of risk or exert a bias away from the null toward an overestimate of risk. Systematic contributors were of more concern because the resulting bias could result in an overestimate of the measure of association. If a study reported an association of an endpoint measure with exposure, confidence was not necessarily decreased if a potential bias was identified that was expected to attenuate the resulting risk estimate. If both exposure and outcome were found to be limited by bias, specifically away from the null, (e.g., found to be deficient), then the confidence in the study was decreased. This was clarified in the revised assessment (see Section 2.3).

- Finding (5): The 2022 Draft Assessment lacks clarity as to how the availability and characteristics of outcome assessment questionnaires were used to rate the confidence level of a study. For example, Mueller and colleagues (2013) provide a reference for their questionnaire, and EPA assessed this study as having a high confidence level. However, Green and colleagues (1989) do not provide a reference for their outcome assessment questionnaire, yet EPA categorized it as well as having a high confidence level (Main Assessment: Table 1-1, pp. 1–18). EPA categorized several studies (Hanrahan et al., 1984; Liu et al., 1991; Sexton et al., 1986) as having medium confidence because of concerns regarding the questionnaires used to assess symptoms without adequate explanation of their deficiencies.

EPA Response to Finding 5: EPA generally considered that the use of a questionnaire for outcome assessment was an adequate measure of outcome assessment given that respondents were blinded to exposure status. Use of a validated, or widely used outcome assessment methodology increased confidence in the outcome measure. Use of unspecified questionnaires increased uncertainty with respect to misclassification of outcome status but was not expected to greatly change the effect estimate. The evaluation criteria for outcome ascertainment using questionnaires have been clarified to indicate that if the questionnaire was less well described, the domain is classified as “adequate” if there is information in the study to conclude that the responses to the questionnaire were not influenced by knowledge of the respondent’s exposure status. Both Hanrahan et al. and Liu et al. did not describe the questionnaire but stated that respondents were blind to their formaldehyde levels. The controlled exposure studies by Green et al. (Green et al., 1987; Green et al., 1989) did not provide a reference for the questionnaire, but described the symptoms assessed including two nonirritant “sham” symptoms to allow an assessment of information bias. In addition, an index of severity also was assessed. While the sensitivity and specificity of the questionnaire was not described, EPA concluded that the misidentification of irritation symptoms by respondents during the experiments was low and the information provided was considered “adequate” to reduce concern regarding information bias. This has been clarified in the revised assessment.

EPA found that “questionnaire” is mentioned only once in the Handbook, and in the Participant Selection section. This is a useful future consideration for EPA to more fully include the occasional use of outcome questionnaires under “outcome ascertainment.”

- Tier 2 Suggested Revision (Recommendation 4.3): EPA should explicitly state what constitutes an adequate assessment of outcomes when a questionnaire is not cited, and explicitly provide the criteria used to determine the adequacy of a questionnaire. Information on these aspects of outcome assessment would facilitate replication of the EPA approach. It would be preferable for EPA to use age categories generally instead of ambiguous descriptors.
  ○ Additional comments on this topic: “therefore, the exposure assessment was not concurrent with the symptoms”… “does not describe the data collection instrument at all, which is seemingly inconsistent with a medium quality rating.”

EPA Response to Tier 2 Suggested Revision 4.3: In the revised assessment, EPA has expanded its description of the study evaluation considerations with information or considerations that would result in a study’s methods for each domain being rated as high, adequate or deficient. For a symptom questionnaire, a validated tool is in the high category; however, an unspecified tool is considered adequate if responses were given without knowledge about the exposure levels experienced. This clarification has been added to the tables in the methods section (Section 2).

- Finding (6): Some studies are potentially affected by multiple limitations. The approach used to classify the level of confidence for such studies is unclear. If there are three sources of potential bias with no apparent directionality (i.e., either over- or underestimation) for each bias, how will the quality of that study be determined? The committee considered as an example the evaluation of the study by Main and Hogan (1983). In Table 1-2 [see report], two problems with this study are identified, with one box fully colored. The classification scheme in Figure II would suggest this study is of medium confidence, but it is classified as having low confidence, presumably because the fully colored box for “other” signifies a greater “degree of limitation.” Additional explanations related to Figure II would make it easier to understand individual study confidence determinations, such as when there is only one potential source of bias, and that bias is likely to overestimate the exposure effect.
- Tier 2 Suggested Revision (Recommendation 4.4): To increase transparency, EPA should document how it assessed the potential for different types of biases, the directionality of resulting biases, and the number of biases, and state how each combination should be interpreted in terms of high, medium, low, or not informative study confidence.
  ○ Related committee comments: “For sensory irritation, EPA needs to clarify how concurrent assessment ensures that exposure preceded health effects for studies in which the outcomes are considered to be acute effects.” “In Table 1-2, where the entry for the Main and Hogan (1983) study shows two sources of biases with one box fully colored. The classification scheme in Figure II would suggest this study is of medium confidence, but a fully colored box likely means something more, which needs to be explained.”

EPA Response to Tier 2 Suggested Revision 4.4: The tables describing the evaluation criteria for each health effect (including specific outcomes) that result in good, adequate or deficient classifications for each domain now clarify how study limitations were evaluated and which were most influential (Section 2.3). The direction of bias was important and is noted if possible. While the classification of a study as low or not informative was not based on a specific number of deficient classifications, generally a bias toward an inflated measure of association would result in low confidence and additional study-specific limitations would result in not informative. The pictorial displays are no longer used to convey the evaluation conclusions, rather, the influential limitations are noted in the summary column with the confidence classification of high, medium or low. Regarding Main and Hogan (Main and Hogan, 1983), the exposed group (administrative employees working in mobile home offices) and the referent group (police officers) were likely dissimilar for a number of attributes associated with the experience of irritation symptoms in their jobs. In addition, the nature of the exposure setting (working in mobile homes versus in the field) raised the potential for the exposed respondents to be aware of their exposure to formaldehyde. These limitations are noted in the study evaluation tables for this study (Appendix B.3).

- Finding (7): The considerations listed for classification of study confidence and evaluation of each study by at least two independent experts is consistent with EPA’s state-of-practice methods.
- Tier 3 Future Consideration (Recommendation 4.5): In the population selection criteria, the potential for selection bias could be assessed by considering the proportion of the eligible population invited to participate in the study and the proportion of the eligible population that was ultimately included in the analysis. EPA should state the criteria used to assess selection bias in the text, tables, and figures.

EPA Response to Tier 3 Suggested Revision 4.5: EPA appreciates this future consideration for potential methods development in evaluating selection bias in individual studies to inform future assessments.

- Un-Tiered Committee Comment on specific study confidence determinations (Appendix E):
  ○ [Liu et al., 1991] “On page A-267 column 2, EPA compared the reporting of asthma prevalence in Liu et al. (1991) (~4 percent) to the national prevalence of asthma at that time and concluded there was “minimal concern for selection bias” in that study. The committee has some concern that this conclusion may not be fully supported. For example, there are several sets of selection factors between the general U.S. population and the study population that need to be considered… At best, the comparison that EPA described in page A-267 for the Liu et al. (1991) study makes a case for the generalizability (external validity) of the findings, if it is assumed that the Liu study sample is representative of the U.S. general population. It does not make a case against selection bias. One argument against selection bias would be to demonstrate that those who participated have comparable characteristics with those who were invited but did not participate. It is also not known how the randomly selected sample compares with the target to the accessible population. If it is not a true random sample, there could be additional potential for selection bias.”

EPA Response to Un-tiered Committee: EPA has revised the evaluation of Liu et al., 1991 to reflect uncertainty regarding differential or nondifferential selection based on knowledge of exposure or symptoms. The conclusion based on asthma prevalence noted above is no longer included in the revised assessment.

##### Related Public Comments

No related public comments were submitted.

#### Evidence Synthesis and Synthesis Judgments

##### Peer Review Findings and Comments

- Finding (8): EPA provides a reasonable basis, one that is consistent with its state-of-practice methods, for labeling as robust the evidence relating formaldehyde exposure and sensory irritation.
  ○ Related committee comments (Appendix C): “For Steps 5 and 6 (synthesis of results and synthesis judgments), EPA was clear about the basis for the strength-of-evidence determination, and it was applied in a way that was consistent with the stated framework. For evidence integration (Step 7), the conclusion was supported by the evidence presented.” AND “The text did not address the strength and precision of the estimates (although this category is not a required criteria to qualify as a robust study, as per Table IV), or the criteria from Table VI that there is “reasonable confidence that chance, bias, confounding, can be ruled out.” Although these criteria are not discussed…” AND “However, the table mistakenly states that there were four high- and medium-confidence residential studies, when there were no high-confidence residential studies (there were four medium-confidence studies). In addition, EPA notes that there were numerous high- and medium-confidence longitudinal (occupational and anatomy lab) studies, but these studies receive limited discussion in the main text. It is unclear why EPA appears to have de-emphasized these studies when evaluating sensory irritation, but then used them as a basis for the robust determination…”

EPA Response to Finding 8: The errors in the evidence integration table have been corrected.

##### Related Public Comments

No related public comments were submitted.

#### Overall Conclusions about the Hazard Descriptor

##### Peer Review Findings and Comments

- Finding (9): EPA’s overall hazard conclusions are supported by the scientific evidence and are consistent with EPA’s state-of-practice methods.

##### Related Public Comments

- Public Comment (American Chemistry Council): “The 2022 Draft Assessment gives equal weight to all the study designs, and simply attributes the variation seen as part of human variability. EPA does not appear to acknowledge that subjective measures can easily be influenced by other factors such as odor perception (Cometto-Muñiz and Cain 1991; Brüning et al., 2014). Six studies were considered for derivation of Points of Departure (PODs) (Hanrahan et al., 1984; Kulle et al 1987; Anderson and Molhave 1983; Liu et al, 1991; Mueller et al., 2013; Lang et al 2008), but only three (Andersen and Molhave, 1983; Hanrahan et al., 1984; Kulle et al 1987 –all medium quality as assessed by EPA, where Andersen and Molhave 1983 was a chapter as opposed to a peer-reviewed publication) were considered for POD derivation in spite of higher quality studies (Lang et al., 2008; Mueller et al., 2013) being available. (Lui et al 1991 was also considered medium quality.)…given the stronger quality of these studies [Mueller et al. 2013 and Lang et al. 2008], RfCs could have been derived from NOELs.”
  “EPA inappropriately dismisses carefully designed chamber studies [Mueller et al. 2013 and Lang et al. 2008].”
  “From the authoritative assessments and reviews published prior to 2019 (ANSES 2018, 2019; Danish Ministry of the Environment 2014; ECHA 2016, 2019; SCOEL 2016; EPA 2008, 2010; WHO 2010), there is a consistent identification of the Lang et al. (2008) and Mueller et al. (2013) studies as key for defining the most sensitive endpoints from which to derive acceptable concentrations of formaldehyde following acute/short-term inhalation exposures. The authoritative bodies identified these two studies because they are high-quality studies, where exposure concentrations were known and controlled, exposures were randomized and double-blinded, and individuals served as their own controls. They noted the studies included both subjective and objective measures, and individuals who were identified as being hyper- or hyposensitive to the effects of formaldehyde. Importantly, there is no evidence indicating an increased sensitivity to sensory irritation to formaldehyde among people often regarded as susceptible (asthmatics, children, and older people) (WHO 2010).”
  “The Draft Assessment sets aside the controlled human chamber studies, in conflict with NAS (2011) recommendations.” [Please see docket for additional details and supporting information.]

EPA Response: To clarify, the IRIS assessment does not apply a reduced UF_H_ for sensory irritation based on subjects being children or asthmatics. In fact, the populations noted as potentially more susceptible to sensory irritation in the UF selection section were smokers, women, those with chronic allergic diseases, and the elderly. The assessment cites specific data from the observational studies modeled to calculate a POD for this endpoint that show such apparent increases in susceptibility.

The assessment makes careful consideration of the controlled exposure studies in human volunteers and derives several candidate values considered for the RfC based on these studies. For the controlled exposure studies, the fact that these experiments only included a very small number of volunteers with quite limited heterogeneity (e.g., all healthy and middle-aged) led to application of the full UF_H_. It is noted that the commenter- indicated studies of healthy, middle-aged (approximately 20–40 year old) volunteers by Lang et al. (2008) and Mueller et al. (2013), the former of 21 men and women and the latter of 42 men with or without nasal hypersensitivity to CO_2_ (not formaldehyde), were considered and not advanced for dose-response analysis. Since release of the external review draft, the IRIS assessment was revised to include tables in Section 5 explaining, study-by-study, why individual studies were or were not advanced for dose-response analysis. The two intentional exposure studies by Lang and Mueller are included in those tables in Section 5.1.1, which now outlines why those studies were not preferred for use in quantitative analyses. Although not advanced, these studies possess similar limitations to the other intentional human exposure studies advanced by EPA (Kulle et al., 1993 and Andersen and Molhave, 1983), and thus identical modeling approaches and UF selections would likely be applied.

Notably, although the PODs are much higher, after applying larger uncertainty factors (e.g., to address interindividual human variability), the cRfCs from the two controlled exposure studies advanced to dose-response analysis for this outcome were generally in agreement with the cRfC based on the residential epidemiology studies (see Section 5.1 in the revised assessment). The decision to select the residential cRfC over cRfCs based on the controlled exposure studies is presented in Section 5.1.4 and aligns with the consensus peer review finding (10).

- Public Comment (Monell Chemical Senses Center): “Formaldehyde has a pungent odor that can be sensed at low ppb levels in air and which at higher concentrations can elicit the onset of sensory irritation; both serve as a warning system of exposure. The lowest potentially undesirable effect levels in humans are generally recognized as odor detection via the olfactory nerve (CN I), resulting in decreased air quality, and following that, eye and nasal tract chemosensory stimulation (i.e., chemesthesis)1. Chemesthetic detection of formaldehyde occurs via cutaneous nerve fibers in the eye and mucus membranes in the nose, via the trigeminal nerve (CN V). This ability to detect formaldehyde or any pungent chemical in the ocular and nasal mucosa represents a normal sensory physiological process and is not tissue irritation (i.e., an inflammatory response) nor an adverse health effect.”
  “Olfactory and chemesthetic detection of formaldehyde can prompt adaptive responses such as preference for mouth vs nasal breathing to reduce unpleasant odor or responses such as eye blinking. However, these sensory responses occur from neuronal stimulation, and are therefore not precursors to an adverse health effect. In contrast, tissue irritation that is related to formaldehyde binding to macromolecules, including protein-protein cross-linking, in nasal epithelial cells, resulting in tissue damage and inflammation is adverse. The differing mode of action for nasal chemesthesis vs nasal tissue irritation represents the difference between a sentinel vs a precursor effect.”
  “From a regulatory viewpoint, the continuum of effects associated with increasing formaldehyde air concentrations can be broken down into a definable sequence: 1) at low concentrations, odor detection and/or sensory chemesthesis or other sensory detection (NOAEL); 2) at higher concentrations, uncompensated upper respiratory tract tissue irritation (the first adverse or critical effect, LOAEL); 3) at yet higher concentrations, cytotoxicity and regenerative hyperplasia (AEL); and 4) at the highest concentrations, potentially nasal tumors (FEL). Consequently, it is important to determine the concentration(s) of formaldehyde that can reliably be associated with non-adverse warning properties such as odor detection and chemesthesis, as well as concentrations objectively causing adverse tissue effects such as cytotoxicity and inflammatory responses.”
  “There is substantial inconsistency in how participant demographics are assessed. The PODs which could be derived based on two considered controlled human exposure studies were rated with less confidence because the study participants were young, healthy volunteers. The more robust studies by Lang et al and Mueller et al (Lang, Bruckner et al. 2008, Mueller, Bruckner et al. 2013) were dismissed for these same reasons and because the USEPA found it ‘difficult to define an adverse response level cutoff for either objective or subjective symptom scores’ (Table 11, p35). However, according to the Hanrahan et al study, “negative coefficients for respondents age were found to be significant for both ocular irritation models, indicating a higher report prevalence in younger persons”(Hanrahan, Dally et al. 1984). The well-established declines in olfactory and trigeminal (chemesthetic) sensitivity with age and age-related diseases means a younger, healthier population (which is typically the demographics of participants in controlled exposure studies) will be most sensitive to the odor and irritancy of formaldehyde (Doty, Shaman et al. 1984, Doty 1989, Wysocki, Cowart et al. 2003).”
  “The Draft Document also marginalizes controlled exposure studies for excluding smokers, perhaps assuming that this is a sensitive subpopulation that should be included. However, smoking decreases the sensitivity of the cornea and conjunctiva (Thomas, Jacob et al. 2012) and smokers’ show reduced nasal/ocular sensitivity to many irritant chemicals (Cometto-Muñiz and Cain 1982, Dunn, Cometto-Muñiz et al. 1982), thus it is appropriate to exclude them in a controlled exposure study where the critical endpoint is sensory irritation. As well, asthma and other health conditions are not considered to predispose individuals to be more sensitive to formaldehyde. Thus, the concerns raised about the populations tested in these well-conducted controlled exposure studies are without merit.” [Please see docket for details and supporting information.]
- Public Comment (American Chemistry Council): “Sensory irritation and other annoyance endpoints are inappropriate endpoints for developing RfCs. Sensory irritation of the eyes and upper airways are not considered adverse by authoritative bodies and reviews (WHO, 2010; Nielsen et al., 2017; ECHA, 2019a). Perception of, or sensory stimulation by, an irritating substance would not be considered adverse as perceptions of, or stimulations by, an unpleasant smell do not affect the form or function of the tissue or organism. Eye and nasal tract chemosensory detection and nerve stimulation that results from inhalation exposure to formaldehyde is an example of chemesthesis. Chemesthesis is a normal physiological response without functional impairment or pathological change. Thus, sensory recognition of formaldehyde is not adverse and is similar to sensory responses to other chemicals or environmental stimuli such as tearing when exposed to fumes from cut onions or blinking when suddenly exposed to sunlight.”

EPA Response (to both public comments above): EPA disagrees that sensory irritation is an inappropriate response for developing an RfC, and this conclusion was supported by NASEM. EPA has retained the same hazard conclusions regarding sensory irritation in the revised assessment. As described in Sections 3.2.1 and 5.1, sensory irritation (e.g., “burning eyes”), at the magnitude and severity reported in most studies, is considered a minimally adverse outcome. However, the quantification of sensory irritation and the noncancer toxicity value for this effect has changed (i.e., the toxicity value is now higher and is no longer one of the health effects supporting the RfC). In accordance with EPA guidelines, once a hazard has been identified, the goal of dose-response analysis is to calculate an RfC that is reasonably protective against those identified hazards, including in susceptible groups. Thus, when selecting studies to support an RfC, in addition to evaluating the study methods, the evaluation also considers the ability of the tested population to address human variability as well as the study-specific-findings (which may differ because of features such as the specific population examined or the study size). This is particularly true for an endpoint such as sensory irritation, which exhibits a large degree of inter-individual variability in sensitivity, and it is even more important when the considered studies are small.

As noted previously, the assessment makes careful consideration of the controlled exposure studies in human volunteers and derives several candidate values considered for the RfC based on these studies. For the controlled exposure studies, the fact that these experiments only included a very small number of volunteers with quite limited heterogeneity (e.g., all healthy and middle-aged) led to application of the full UF_H_. It is noted that the commenter- indicated studies of healthy, middle-aged (approximately 20–40 years old) volunteers by Lang et al. (2008) and Mueller et al. (2013), the former of 21 men and women and the latter of 42 men with or without nasal hypersensitivity to CO_2_ (not formaldehyde), were considered and not advanced for dose-response analysis. Since release of the external review draft, the IRIS assessment was revised to include tables in Section 5 explaining, study-by-study, why individual studies were or were not advanced for dose-response analysis. The two intentional exposure studies by Lang and Mueller are included in those tables in Section 5.1.1, which now outlines why those studies were not preferred for use in quantitative analyses. Although not advanced, these studies possess similar limitations to the other intentional human exposure studies advanced by EPA (Kulle et al., 1993 and Andersen and Molhave, 1983), and thus identical modeling approaches and UF selections would likely be applied.

With few exceptions (i.e., large population studies encompassing a wide range of demographics, including reasonable representation of known or expected susceptible groups), the available studies are judged as unlikely to sufficiently address the identified differences in susceptibility described in Section 4.1 of the Toxicological Review. Also, as outlined in greater detail in other EPA responses, characterizing sensory irritation as a non-adverse “warning property” occurring at lower formaldehyde levels than those causing other health effects is not supported by the data. Thus, protecting against this response, especially based on acute exposure in healthy volunteers, would not be expected to protect against other chronic health effects, including cancer (particularly when considering human variability).

However, although the PODs are much higher, after applying larger uncertainty factors (e.g., to address interindividual human variability), the cRfCs from the two controlled exposure studies advanced to dose-response analysis for this outcome were generally in agreement with the cRfC based on the residential epidemiology studies (see Section 5.1 in the revised assessment). The decision to select the residential cRfC over cRfCs based on the controlled exposure studies is presented in Section 5.1.4 and aligns with the consensus peer review finding (10).

#### Dose-Response Evaluation

##### Peer Review Findings and Comments

- Tier 2 Suggested Revision (Recommendation 4.6): EPA should clarify and clearly state the criteria used to select the studies for dose-response analysis of noncancer endpoints.
  ○ Related committee comments (Appendix C): “the recommendation of the 2014 National Research Council (NRC) report to use data from multiple studies when possible.” … “The committee notes the complementarity of the two studies [Liu and Hanrahan] and the broadening of the range of exposures considered in the combined analysis.” [Note: an initial approach to this estimation for sensory irritation specifically was outlined by the committee in Appendix D of the report].
  ○ Related committee comments (Appendix C): “categories of Overall Confidence Conclusion, Study Confidence, Population, and Exposure Information [are described; see also Table C-3],… although EPA did not provide further descriptions of those considerations to aid in interpretation of how they were applied.”…“The text of the Preface provided further considerations for study selection …stating that EPA puts particular emphasis on the accuracy of formaldehyde exposure, the severity of the observed effects, and the exposure levels analyzed.” … “For sensory irritation, it stated that studies that conducted the exposure assessment concurrently with the outcome assessment were the most informative for RfC derivation because formaldehyde induces a rapid irritant response.” …“EPA concluded that the Hanrahan exposure assessment “reflect[ed] the usual, relatively constant formaldehyde concentrations in the residences” (p. 2-9), which is not supported by the short duration and the single occasion when measurements were taken.”
  ○ Related committee comments (Appendix C): “The committee finds that the 2022 Draft Assessment does not adequately acknowledge the full scope of uncertainty associated with the Hanrahan et al. dose-response relationship.”
  ○ Related committee comments (Appendix E): “Regarding sensory irritation, in Tables 1-1 and 1-2, several studies have been identified as high or medium confidence, but only six were included in the sensory irritation dose-response analysis (Table 2-1). It is unclear why only these six studies were chosen.”

EPA Response to Tier 2 Suggested Revision 4.6: EPA has expanded the description in the assessment methods in Section 2.7 to detail how studies are evaluated against multiple considerations to determine which studies are best suited for advancement to dose-response analyses. In addition, expanded tables on study selection for each health outcome have been added to the dose-response section (Section 5 of the revised assessment) to reflect study performance against those considerations. [Note: The BMD Technical Guidance (Section 2.1.3) states: “Following a complete review of the toxicity data, the risk assessor selects the studies for BMD analysis, based on the human exposure situation being addressed, the quality of the studies, the reporting adequacy, and the relevance of the endpoints. The process of selecting studies for BMD analysis is intended to identify those studies for which modeling is feasible, so that BMDs can be calculated. All relevant studies should be considered for modeling. In some cases, the selection process will identify a single study or very few studies for which calculations are appropriate. In other cases, there may be a number of studies, or studies with a number of endpoints reported, which may require a large number of BMD calculations. In these latter cases, it may be possible to select a subset of endpoints as representative of the effects in a target organ or study. This selection can be made on the basis of sensitivity or severity, which may be more easily compared within a single study in the same target organ than across studies. Sometimes combining several datasets may be an option.”]

In Section 5.1.1, EPA documents the strengths and concerns with using each of the high and medium confidence studies of sensory irritation in dose-response analysis, including Hanrahan et al. (1984) and Liu et al. (1991). There were some concerns noted for both of these studies, including that neither provided the regression parameter details in their publications. The two studies used different methods for exposure assessment, had different LODs, and had different age distributions. However, these differences complemented each other.

The 2014 National Research Council (NRC) report recommended that dose-response estimation be based on data from compatible studies of similar exposure and outcome when feasible and the specific idea to estimate the dose-response function from the combination of these two studies was recommended by NASEM. Following NASEM’s example, EPA now derives a toxicity value from the combination of these two studies. Using this approach, EPA was able to derive a POD for sensory irritation and considered that osRfC in place of the draft osRfC based on Hanrahan et al. (1984) alone.

- Finding (10): EPA’s favoring of well-conducted and -reported epidemiologic studies over controlled human exposure studies was justifiable for sensory irritation.

##### Related Public Comments

- Public Comment (American Forest and Paper Association): “EPA’s reliance on residential or home studies is misguided and is not the Best Available Science.” “EPA should rely on human volunteer chamber studies that have proper controls to reduce or eliminate confounding factors and false positives.” “EPA fails to rely on Mueller et al. 2013 and Lang et al. 2008, that are considered by many countries as ‘critical studies’ (e.g., France, Netherlands, 2019)” “EPA’s representation of the sensory irritation studies as an adverse health effect cannot be considered the best available science.” [Please see docket for details and supporting information.]

EPA Response: Please see the consensus peer review Finding 10. Consistent with this recommendation, the revised assessment continues to emphasize the epidemiologic studies over the human volunteer chamber studies for this health effect and in deriving candidate lifetime toxicity values. Expected differences in susceptibility and interindividual variability in the sensory irritation response (described in Sections 3.2.1 and 4.1) were impactful to the dose-response study selection uncertainty factor decisions (see also responses to related public comments earlier in this section, Appendix F.3.2). The dose-response decisions and the supporting rationale for these decisions are described in Section 5.1, with the reasons for not advancing the studies by Mueller et al. 2013 and Lang et al. 2008 articulated therein (in Section 5.1.1). However, two chamber studies (Kulle et al., 1993 and Andersen and Molhave, 1983) were modeled and discussed in comparison to the results from modeling of the two residential studies (Liu et al., 1991 and Hanrahan et al., 1984) advanced for dose-response analysis. Specifically, regarding support for the identification of sensory irritation as a health effect of concern for formaldehyde inhalation exposure (Section 3.2.1), Finding (9) from the NASEM report indicates, “EPA’s overall hazard conclusions are supported by the scientific evidence and are consistent with EPA’s state-of-practice methods.”

### F.3.3 Pulmonary Function

#### Charge Question and Peer Review Comment Summary

##### Charge Question 3b. Pulmonary Function

- The assessment concludes that the available evidence indicates that long-term formaldehyde inhalation likely causes decreased pulmonary function in humans given appropriate exposure circumstances. This conclusion was supported primarily by evidence in exposed humans, with supportive mechanistic evidence indicating that formaldehyde inhalation results in biological changes related to this outcome.
- The assessment concludes that the available evidence is inadequate to determine whether acute or short-term (hours to weeks) formaldehyde inhalation might cause decreased pulmonary function in humans.
- A POD from Krzyzanowski et al. (1990), a human study, was ultimately selected to calculate an osRfC of 0.007 mg/m^3^ for pulmonary function. A composite UF_C_ of 3 was applied to address UF_H_. This UF_H_ value was selected using available evidence on potential susceptibility including consideration of children’s health.

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 8 Consensus Panel Findings (numbered below)

#### Literature Identification

##### Peer Review Findings and Comments

- Finding (1): The inclusion and exclusion criteria listed in Appendix A, Table A-42 are consistent with EPA’s state-of-practice methods.

##### Related Public Comments

No related public comments were submitted.

#### Study Evaluation

##### Peer Review Findings and Comments

No Findings or Recommendations specified.

##### Related Public Comments

No related public comments were submitted.

#### Evidence Synthesis and Synthesis Judgments

##### Peer Review Findings and Comments

- Finding (2): Within study groupings, EPA equates a lack of statistical significance with a lack of decline in pulmonary function (e.g., reference to Lofstedt PDF p. 98, line 19), and makes statements that are poorly supported by the evidence (e.g., reference to the size of differences and lack of precision on PDF p. 101, line 7).
- Finding (3): Evidence is presented inconsistently across the six sections describing results from different exposure durations and study populations.
- Finding (4): Overall, while EPA’s distillation and synthesis of the pulmonary function evidence is challenging to follow, the judgments presented in the Main Assessment are supported by the scientific evidence and consistent with EPA’s state-of-practice methods.
  ○ Related committee comments: “Small declines in pulmonary function can have a large impact on public health, regardless of whether individual declines are clinically significant.”
- Finding (5): Given the wording in Section 3.2.3, it is difficult to understand the basis for some of the evidence synthesis judgments as presented in the Assessment Overview. For example, EPA does not provide the specific evidence and decision frameworks used to support the following statement: “overall the longitudinal analyses appear to be inconsistent, but while hindered by a lack of sensitivity, seem to support a conclusion that occupational exposure may result in declines of FEV1 and FEF over time” (p. 53, line 17). Further, some aspects of the study synthesis discussion are not clearly defined. For example, what does it mean that studies observed “inconsistent responses” (Assessment Overview p. 52, line 10)? Does this mean that reported results are in different directions, or that some results are statistically significant, while others are not?
- Tier 2 Suggested Revision (Recommendation 4.7): EPA should clarify the basis for its synthesis judgments and provide additional information about the studies on which they are based, such as the formaldehyde levels observed, as well as the exposure ranges or other measure of variability. The study summary tables (Tables 1-6 to 1-9) should be updated to provide an organized distillation of the points made in the evidence synthesis text.
  ○ Related committee comments: “The synthesis discussion is blended with the study evaluation tables (Tables 1-6 to 1-9) also presented in this section, and the subsection is organized by exposure duration…” AND, [in reference to acute exposure]: “studies that did include a referent group showed a change in pulmonary function on average in that group, although studies varied with respect to the direction observed, and this additional potentially insightful detail is not provided.” AND [in reference to intermediate duration exposure in pathology students]: “These studies are not mentioned further in any of the summaries (i.e., t…the integrated summary of evidence in the Main Assessment)” AND [in reference to long-term occupational exposures]: “Long-term occupational: “reference to cross-sectional studies (Main Assessment, p. 102) points to studies under the “prevalence studies” heading in Table 1-7; it is left to the reader to make this connection.” “Figure 1-6… would benefit from more in-depth discussion.”
  ○ Related committee comments: “[The evidence profile table mentions] several studies of workers with long-term exposure to >0.2 mg/m3” without giving references. EPA also concluded that the evidence is inadequate to determine the causal effect of formaldehyde exposure on acute and intermediate-term time scales. This judgment does not give much weight to the evidence that pulmonary function decrements occurred in controlled human exposure settings among participants who exercised at least 30 minutes (Green et al., 1987, 1989), or that some individuals exhibited clinically significant deficits (Green et al., 1987).”
  ○ Related committee comments (Appendix E): “Regarding pulmonary function, Table 1-11 indicates there are multiple additional studies included in the evidence judgment for long-term effects, although none of these are referenced. The evidence cited in the table and narrative need to be revised to provide more informative statements. For instance, “concentration-related associations” would preferably be rephrased as “concentration-related decrements in lung function.”
  ○ Related committee comments (regarding Figure 1-5): EPA needs to order the studies within industry by formaldehyde exposure levels, or the exposure difference between groups; EPA needs to improve the labeling of the figure to provide clarity, such as by indicating that the numbers before the plotted results refer to sample sizes;tThe text refers to Figure 1-5 summarizing ten studies, while the figure caption notes there are eight; Clarity would be improved by ensuring that the comparison being reported (i.e., pre-shift pulmonary function differences in prevalence studies) is clearly stated in the caption and accompanying text. Reference information is needed for the study discussed on page 1-45, lines 11-15, and the study referred to as “this study” on line 15.
  ○ Related committee comments: The pulmonary function section would benefit from a summary table that refers to all summarized studies and provides an organized distillation of the points made in the text.
  ○ Related committee comments: Tables need to be formatted clearly to correspond to the information highlighted in the synthesis discussion (e.g., for pulmonary function, which occupational studies had employees that worked at least 5 or at least 10 years—see the Assessment Overview, p. 52, line 33; or indicate the main conclusions EPA reached for each group of studies).

EPA Response to Tier 2 Suggested Revision 4.7: The revised assessment includes summary sections on the evidence synthesis conclusions for each health effect, which are supported by evidence tables (note: these are distinct from the study evaluation tables in the Appendices). This includes context on formaldehyde exposure levels, if it was deemed appropriate to include such statements prior to performing dose-response analyses.

The study selection criteria (PECO) included studies of pulmonary function responses to any exposure duration. EPA recognizes that presentations were somewhat inconsistent across the discussion by exposure setting and duration, reflecting the differences in relevance to the development of a RfC for chronic health effects. In the revised assessment, EPA has refocused the synthesis on exposure settings most relevant to the dose-response assessment and derivation of a RfC for chronic duration exposure scenarios. These studies include the occupational studies of workers with long-term exposure, residential or school exposures to adults or children, and episodic (weekly) exposures to medical students in anatomy classes followed over a period of months. Results of studies of other exposure scenarios involving short-term exposure durations are not directly relevant to a chronic duration RfC. Moreover, these results did not provide a clear indication of effects on pulmonary function and EPA has removed the hazard evaluation for short-term/acute effects. However, these results are summarized in the appendix (see Appendix C.5 for studies of workers or medical students and pulmonary function changes across a work shift or over a dissection lab). For each exposure setting (i.e., occupational, residential, anatomy class) the synthesis discussion is oriented around the consistency of evidence across studies, evidence from different study designs (e.g., cross-sectional studies, longitudinal studies) and the interpretation of results in light of potential biases, strength of results and evidence for dose-response.

The synthesis discussion has been edited for clarity and references have been added to support specific synthesis statements. Statements were edited to improve clarity. The levels of formaldehyde experienced in each occupational exposure setting are described. The proposed draft provided overall exposure levels reported for the occupational studies, but EPA has edited the synthesis to provide more detail regarding levels in each of the three industry groupings studied: wood products, chemical manufacture, and embalming. Figure 3-5 (in the revised assessment) was not altered to order the studies by average exposure levels because the time weighted averages reported by many of the occupational studies did not characterize well the exposure levels experienced. There were wide ranges of levels reported within each study so ordering the studies by average levels would not have clarified the analysis. The study results are grouped by industry.

- Tier 2 Suggested Revision (Recommendation 4.8): If the Assessment Overview is retained (see Recommendations 2.1 and 2.2 in Chapter 2), EPA should harmonize its presentation of evidence synthesis with the presentation in the Main Assessment. In particular, the evidence synthesis section of the Assessment Overview could be updated to build upon the first three paragraphs of the “Integrated Summary of Evidence for Pulmonary Function” section in the Main Assessment (PDF p. 134).

EPA Response to Tier 2 Suggested Revision 4.8: The Assessment Overview was not intended as a separate documentation of EPA’s analyses. Rather, the Overview was included to provide a summary of the primary conclusions in the Toxicological Review and Appendices for audiences not interested or able to consult the lengthy Toxicological Review. The Overview has not been retained as part of the revised assessment.

- Finding (6): The MOA considerations and mechanistic evidence are clearly presented and appropriately documented.

##### Related Public Comments

No related public comments were submitted.

#### Overall Conclusions About the Hazard Descriptor

##### Peer Review Findings and Comments

- Finding (7): EPA’s evidence integration judgments are supported by the scientific evidence and are consistent with EPA’s state-of-practice methods.

##### Related Public Comments

No related public comments were submitted.

#### Dose-Response Evaluation

##### Peer Review Findings and Comments

- Finding (8): EPA’s derivation of BMCL was based on nonasthmatic children and nonmorning exposures. This practice was inconsistent with EPA’s state of the practice of using more vulnerable subpopulations for risk estimation.
- Tier 2 Suggested Revision (Recommendation 4.9): EPA should provide additional justification for why the most vulnerable subpopulations were not used for risk estimation, and should consider using the data from children with asthma that are provided in Krzyzanowski et al. (1990).

EPA Response to Tier 2 Suggested Revision 4.9: EPA estimated the BMC and BMCL for all children and noted that Krzyzanowski et al. (1990) found that asthmatic children showed a steeper decline in morning peak expiratory flow rate (PEFR) compared with nonasthmatic children. The model shown in Table 5 of Krzyzanowski et al. (1990) did not include a main effect parameter for ‘asthma’ because it was not statistically significant. The model did show statistically significant parameter estimates for a quadratic function of (Bedroom HCHO)*’morning’*’asthma’ and EPA was able to estimate a BMC for asthmatic children’s PEFR measured in the morning after assuming that Bedroom and Household HCHO were equal and that the main effect parameter for ‘asthma’ was zero. The BMC was lower for asthmatic children’s PEFR measured in the morning than for all children. In order to estimate a BMCL for these children, EPA would need to know the standard error of the summary effect estimate for HCHO in these children. Summing only the standard errors terms in the model ignores that complexities of the covariances between the several related variables. EPA contacted Dr. Krzyzanowski regarding further details of the regression model, but no additional documentation is available (cite email). Thus, the POD derived from Krzyzanowski et al. (1990) for decrements in pulmonary function is based on data for all children in the study, not asthmatic children alone. In applying UFs to this POD to calculate a cRfC, because it was demonstrated that the effect of formaldehyde exposure on asthmatic children’s PEFR was more sensitive than all children, an uncertainty factor for human variability of 3 was applied to address the increased sensitivity of asthmatic children.

##### Related Public Comments

- Public Comment (American Chemistry Council): “The Draft Assessment did not present an alternative to the RfC based on Krzyzanowski et al. (1990), as directed by the NAS (2011) and does not address the inherently limited reliability of the cross-sectional study design of the study and classified the study confidence as ‘high.’”
  “These contradictions and “plausible” speculations do not inform an evidence-based assessment. If there is no dose-response, not time concordance, and no mode of action for the observed effects, no pathological basis for the effects, and no distribution to the [lower respiratory tract], there is no support for any cause-and-effect relationship. The Draft Assessment would be improved by simply stating the evidence for and against causal association, without speculation about plausibility of undefined causes.” [Please see docket for details and supporting information.]

EPA Response: Consistent with recommendations from the consensus peer review panel, the revised assessment continues to retain the same hazard judgment for pulmonary function (Section 3.2.2) and continues to rely on dose-response analysis based on the study by Krzyzanowski et al. (1990), noting that the RfC is not based on this study alone (Section 5.1.5). Attempts to incorporate modeling for a sensitive subgroup in this study (i.e., asthmatic children), as recommended by the NASEM panel and which would have resulted in a lower point-of-departure, were unsuccessful as the required information to estimate a BMCL were not available in (Krzyzanowski et al., 1990; Krzyzanowski and Bateson, 2023).

As described in the Assessment Methods (Section 2) and consistent with EPA guidelines, understanding of MOA is not required to identify a hazard (or to support subsequent dose-response analysis for identified hazards). It is noted that for pulmonary function, however, a partial MOA was in fact identified and, although inhaled formaldehyde is unlikely to reach the lower respiratory tract in most exposure scenarios, inflammation and other changes in the lower respiratory tract are well supported (see MOA summary in Section 3.2.2).

EPA notes that varied epidemiological study designs, not only cross-sectional studies, were available to support the hazard determinations for pulmonary function as well as the other identified hazards. It is important to emphasize, however, that well-conducted studies with a cross-sectional design can address causation, including the temporality concern raised by the commenter above. This is the case if the study’s measurement(s) of exposure address the etiologically relevant time-period for the outcome under review. Additional discussion and explanation on this well-established epidemiological principle has been added to Sections 2 and 3 of the Toxicological Review. The IRIS assessment paid significant attention to the exposure measurement design and quality during study evaluation. Although this was already discussed in Section 2 and detailed in Appendix B.3 in the public comment/external peer review draft, the final assessment now includes an expanded discussion and rationale on this point in Section 2. Namely, through the extensive analyses of the available epidemiology studies meeting the PECO criteria as well as numerous supplemental resources, the assessment focuses on epidemiological studies with measures of formaldehyde exposure of 5–7 days or more as a high-quality exposure assessment representative of exposure levels over the preceding weeks and months. Studies such as Krzyzanowski et al. (1990) with the additional attribute of including formaldehyde measures across multiple seasons provides additional confidence in the interpretation of the measures as representing longer term past exposures. These measurements reflecting long-term, ongoing formaldehyde exposure levels are most useful in developing the chronic RfC and IUR. Exposure assessments of longer duration and in multiple periods provide more precise estimates of longer-term exposure and there is greater confidence in PODs based on them. Overall, 3 of 6 cross-sectional studies on pulmonary function among adults and children had high quality exposure measures and two studies had adequate exposure assessments; these 5 studies were interpreted with high or medium confidence. One study had deficient exposure quality and was interpreted with low confidence.

Specifically, for Krzyzanowski et al. (1990), the assessment now includes more frequent highlighting of the details of the study that support the high confidence rating. The study used a strong design and analysis, including two daily measurements of pulmonary function over a 12-day period and a high-quality exposure assessment. Since there was not a trend in the average daily peak expiratory flow rate (PEFR) measurements over the 12 days of testing, the 12-day average of PEFR in an individual reasonably represented the current average pulmonary function for the children and adults at the time of the study. The association observed in children with formaldehyde concentrations averaged over two 1-week sampling periods (with a subset of samples collected across different seasons) indicates a persistent effect of formaldehyde exposure. The assessment has added details from the supporting study, (Quackenboss et al., 1989), which shows that average formaldehyde measurements in the homes during the first and second sample weeks were highly correlated, and that this pattern was consistent within each of the sampling locations, with none of the week-to-week differences being significantly different. This shows that the exposure indices based on one-week samples or by averaging over two, one-week samples to obtain a single HCHO concentration index (i.e., an index for each household average and separately for each person’s bedroom) were stable over time, and this supports that these indices reasonably reflect past exposures. Thus, these exposure measurements reliably represent average formaldehyde levels relevant to both the short-term timeframe of the pulmonary function measures as well as the months prior to those outcome measurements. These exposure measurements are of clear etiological relevance.

### F.3.4 Respiratory Pathology

#### Charge Question and Peer Review Comment Summary

##### Charge Question 3e. Respiratory Tract Pathology

- The assessment concludes the evidence demonstrates that inhalation of formaldehyde causes respiratory tract pathology in humans, given sufficient exposure circumstances. Well-conducted studies in humans and animals support this hazard conclusion, and strong mechanistic evidence in animals provides a plausible MOA for the identified outcomes.
- PODs from the Kerns et al. (1983) and Woutersen et al. (1989) rat studies were ultimately selected to calculate an osRfC of 0.003 mg/m^3^ for squamous metaplasia. The PODs were estimated using dosimetric simulations of formaldehyde flux to the nasal lining using a computational fluid dynamics model to extrapolate from results in rats to humans. A composite UF_C_ of 30 or 100 was applied to address UF_H_, subchronic (UF_S_) and interspecies (UF_A_) uncertainties.

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 2 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 6 Consensus Panel Findings (numbered below)

#### Literature Identification

##### Peer Review Findings and Comments

- Finding (1): For human studies, the comparator of the PECO is defined as evaluated outcome associations with formaldehyde exposure; it is unclear what specific comparisons were made. The comparator in the PECO statement used for screening the animal studies is undefined.
- Finding (2): It is unclear why EPA did not consider more distal effects in the respiratory tract since studies performed in nonhuman primates have reported changes in the respiratory epithelium of the trachea and major bronchi (Monticello et al., 1989). The exclusion criteria for human respiratory tract pathology included exclusion of studies reporting rhinitis. This exclusion is surprising since rhinitis was a search term used to find human studies. Moreover, it is unclear whether this exclusion criterion resulted in exclusion of studies with histologic evidence of inflammation.
- Tier 2 Suggested Revision (Recommendation 4.10): EPA should provide an explicit description of the comparator used in screening human and animal studies, and resolve discrepancies between search terms and inclusion and exclusion criteria.
  ○ Related committee comments (Appendix E): “For respiratory pathology, it is unclear how search terms were used (e.g., controlled vocabulary [MeSH] and keyword terms).”

EPA Response to Tier 2 Suggested Revision 4.10: In reference to the comparator, EPA has provided a revised definition consistent with the IRIS Handbook in the revised draft: “evaluated outcome associations with formaldehyde exposure risk in relation to variation in exposure based on level, duration, or other parameter.” In reference to the outcome domain (presumed to be in reference to the search of human studies as the animal search explicitly included distal sites), the assessment methods have been clarified to explain the focus on proximal effects on the respiratory system in humans as more distal evaluations of pathology are highly invasive and thus not well-studied (note: BAL is a noninvasive marker of potential distal/pulmonary injury; however, BAL endpoints were captured in the mechanistic search related to inflammation and immune responses). Signs such as rhinitis or mucous flow rate were included in the discussion of mechanisms of inflammation and immune system responses; this has been clarified in the revised assessment.

All search strings were submitted as keyword searches, which in the case of PubMed includes MeSH terms by default, except as specified with tags like [majr] which limited the search to only when the term (and any selected subheadings) are indexed as a major topic heading (not all MeSH terms); as defined by PubMed, a MeSH Major Topic is one of the main topics discussed in an article.

##### Related Public Comments

No related public comments were submitted.

#### Study Evaluation

##### Peer Review Findings and Comments

- Finding (3): EPA’s outcome-specific criteria are generally appropriate and consistent with its state-of-practice methods. It is unclear whether the downgrade for cross-sectional studies among occupational cohorts is relevant for histopathologic outcomes. Evidence supporting consideration of gender as a confounder is not provided. For animal studies, sample size limitations were applied inconsistently. In general, EPA was also inconsistent in providing a rationale for each study quality domain (Appendix A, Table A-59), reducing transparency.
- Tier 2 Suggested Revision (Recommendation 4.11): EPA should provide a consistent rationale for each study quality domain used in the assessment.
  ○ Related committee comments: “EPA downgraded cross-sectional studies among occupational cohorts since workers may have been less sensitive to the irritant properties… EPA did not critically evaluate whether a health worker survivor effect was present in these studies” Note also: “sample size of less than 10 was considered a significant limitation”; however, this criterion was applied to the Holmstrom et al. (1989) study even though this study had 16 animals”

EPA Response to Tier 2 Suggested Revision 4.11: The evaluation criteria for occupational studies of formaldehyde exposure and respiratory outcomes have been revised so that a potential “healthy worker” (survival) effect does not automatically result in a low study confidence. Since any bias, if present, would result in an underestimate of effect estimates, it was noted in the study evaluation tables, but did not result in low confidence based on that limitation alone. While critical evaluation of the studies of respiratory pathology for evidence of survival bias was not possible, information was provided in studies of other health effects that allowed a more specific evaluation of the evidence for survival bias, which was noted in the study evaluation tables. As is shown in these evidence tables within Section 3.2.4, for the small number of human studies of respiratory pathology (all medium confidence studies of occupational formaldehyde exposure), this change did not influence the evidence synthesis conclusions or associated uncertainties. It is noted that this potential bias attenuates, or underestimates, effect estimates and yet the majority of available studies still observed effects of formaldehyde exposure. Also, gender was removed as a potential confounder for effects on nasal pathology, as no support was found.

For animal studies, NASEM noted N = 10 was considered a limitation and used the downgrade of Holmstrom (1989) with N = 16 animals as a source of inconsistency. However, to clarify, the sample size consideration based on the OECD guideline study design differs between chronic and subchronic studies, requiring N > 20 for a chronic study and N > 10 for a subchronic study. As Holmstrom (1989) was a chronic study, N = 16 animals was appropriately noted as a limitation. However, the study evaluations were reviewed and revised for consistency.

Note that for animal studies throughout the assessment, when the study methods met the domain-specific criteria the symbol ‘++’ for ‘Good’ was used and no further domain-specific explanation was provided. Study-specific details that resulted in a lower rating ‘Adequate’ (shading of ‘+’) are italicized within each domain-specific cell in the table. When a rating of ‘Deficient’ (symbolized by a gray-shaded cell) was noted, the study-specific detail that caused that rating is bolded within each domain-specific cell. Notes about study details that did not alter the domain-specific ratings but which may be informative to the evidence synthesis are sometimes included. This has been made clearer in the revised assessment.

##### Related Public Comments

No related public comments were submitted.

#### Evidence Synthesis and Synthesis Judgments

##### Peer Review Findings and Comments

- Finding (4): The judgments presented in the Main Assessment are supported by the scientific evidence and consistent with EPA’s state-of-practice methods.

##### Related Public Comments

No related public comments were submitted.

#### Overall Conclusions About the Hazard Descriptor

##### Peer Review Findings and Comments

- Finding (5): The evidence integration judgments made by EPA are supported by the scientific evidence and consistent with EPA’s state-of-practice methods.

##### Related Public Comments

No related public comments were submitted.

#### Dose-Response Evaluation

##### Peer Review Findings and Comments

- Finding (6): EPA’s dose-response evaluation was well documented and transparent. Steps used are consistent with EPA’s state-of-the-practice.
  ○ Related committee comments: “[EPA] did not explain why its confidence in the POD based on the Woutersen et al. (1989) study was medium.”

EPA Response to committee comments related to Finding 6: The confidence classification for this candidate toxicity value is “Medium-high” in the revised assessment. As now documented in Section 5.1.4, the following concerns relating specifically to the POD have been added: Smaller study (as compared to Kerns et al., 1983) can introduce increased variability; no exposure levels between 1.2 and 11.2 mg/m^3^ (which introduces uncertainty regarding the shape of the curve between those levels), and default dosimetric extrapolation (as compared to the ability to apply dosimetric modeling approaches for Kerns et al., 1983). However, Woutersen et al. (1989) remains the selected cRfC for this health effect-specific toxicity value (the osRfC) in the revised assessment.

##### Related Public Comments

No related public comments were submitted.

### F.3.5 Allergy and Asthma

#### Charge Question and Peer Review Comment Summary

##### Charge Question 3c. Allergy-related Conditions

- The assessment concludes that the available evidence indicates that formaldehyde inhalation likely causes increased allergic responses in humans, given appropriate exposure circumstances. This conclusion was supported primarily by evidence in exposed humans, with supportive mechanistic evidence indicating that formaldehyde inhalation results in biological changes related to this outcome.
- A POD from Annesi-Maesano et al. (2012), a human study, was ultimately selected to calculate an osRfC of 0.008 mg/m^3^ for allergy-related conditions. A composite UF_C_ of 3 was applied to address UF_H_. This UF_H_ value was selected using available evidence on potential susceptibility including consideration of children’s health.

##### Charge Question 3d. Prevalence of Current Asthma and Degree of Asthma Control

- The assessment concludes that the available evidence indicates that formaldehyde inhalation likely causes an increased frequency of current asthma symptoms or difficulty controlling asthma, given appropriate exposure circumstances. This conclusion was supported primarily by evidence in exposed humans, with supportive mechanistic evidence indicating that formaldehyde inhalation results in biological changes related to these outcomes.
- PODs from the Annesi-Maesano et al. (2012), Krzyzanowski et al. (1990), and Venn et al. (2003) human studies were ultimately selected to calculate an osRfC of 0.006 mg/m^3^ for current asthma or degree of asthma control. A composite UF_C_ of 3 or 10 was applied to address UF_H_. The UF_H_ value applied to the POD from Annesi-Maesano et al. (2012) was selected using available evidence on potential susceptibility including consideration of children’s health.

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 1 Un-tiered Committee Comment
- 11 Consensus Panel Findings (numbered below)

#### General Scope and Approach

##### Peer Review Findings and Comments

- Finding (1): Allergies and asthma as systemic immunopathologies related to inhaled formaldehyde are well documented in the 2022 Draft Assessment. It is unclear whether additional systemic immune-mediated diseases (e.g., contact allergy, immunodeficiencies, lupus, rheumatoid arthritis) were also considered and rejected because of a lack of relevance or information.
  ○ Related committee comments: “Although it is a portal-of-entry effect, the committee’s discussion concerning asthma is included in the evaluation of systemic effects, reflecting the broader inflammatory consequences of asthma.”

EPA Response to committee comments related to Finding 1: Acknowledging the systemic inflammatory consequences, EPA continues to discuss allergy in asthma as effects on the respiratory system, consistent with the committee’s statement that these are POE effects. EPA did not include search terms relating to autoimmunity, autoimmune conditions such as systemic lupus erythematosus and rheumatoid arthritis or conditions relating to immunodeficiency because these had not been discussed in any of the reviews or previous risk assessments that were consulted. It is likely that the broad net used by EPA would have collected studies on these topics, since a variety of immune-related terms were used. However, no research articles on these topics in relation to formaldehyde exposure were noted by the screeners.

- Tier 2 Suggested Revision (Recommendation 4.12): EPA should provide a comprehensive description or listing of immunopathologies that were considered as potentially related to formaldehyde before the decision was made to limit the focus to prevalent allergies and prevalent asthma.

EPA Response to Tier 2 Suggested Revision 4.12: As discussed and now more specifically documented in the Assessment Methods (Section 2), the outcomes were selected based on prior risk assessments of formaldehyde and the NRC (2011) review of a prior EPA draft assessment. Note that, in addition to the more narrow focus of the search for epidemiology studies, a broad search of information relevant to inflammation or immune responses was conducted and documented. No additional immunopathologies of potential concern were highlighted based on that broader review.

##### Related Public Comments

No related public comments were submitted.

#### Literature Identification

##### Peer Review Findings and Comments

- Finding (2): The considerations and methods adopted by EPA were appropriate given the often poor specificity of diagnostic classifications in the published literature on these conditions. Study choice decision metrics are adequately described.
- Finding (3): The terms “very young” and “very old” (as exclusion criteria) are not defined, and several studies of school-age children were used to inform the strength-of-evidence determination. While age cutoffs of <5 and >75 years are cited in the Assessment Overview and Appendices as exclusion criteria, the Main Assessment does not describe age cutoffs, and it is unclear how these cutoffs were made actionable in study choice as some studies of infants and children <5 feature in asthma evaluations in particular. “Infants” (again, a specified age needs to be given each time this word is used) were deemed to have nonspecific symptoms (wheeze and infection) compared with adults and were not considered in the formulation of PODs or synthesis judgments. Likewise, the “elderly” (assumed to mean >75, but again, age needs to be specified each time the word is used) were not considered because of the potential interference of alternative mechanism diseases such as chronic obstructive pulmonary disease (COPD). In general, EPA divided evaluations into “child” and “adult” studies, but age cutoffs for these categories need to be stated and applied consistently.
- Finding (4): EPA’s decision to exclude food allergy in response to airborne formaldehyde while including eczema is not explained. The rationale for excluding formaldehyde-specific immunoglobulin E (IgE) as an endpoint (because of its rarity in evaluation) is explained appropriately.
- Finding (5): The inclusion/exclusion criteria for animal studies are described in confusing terms. While the search terms emphasize biological mechanisms as relevant (biomarkers such as immunoglobulin G (IgG), IgE, cytokines, hypersensitive reactions), EPA also states that studies “describing the development of immunological or allergy animal models” were not included (Appendix A, p. A-337). The 2022 Draft Assessment documents that animal models are generally helpful only in immediate pathological response to formaldehyde rather than the development of disease states that recapitulate human diseases, but a clear reason for excluding animal models of “the development of immunological or allergy” outcomes is not provided.
- Tier 2 Suggested Revision (Recommendation 4.13): EPA should explicitly state its rationale for age-based exclusions and define the terms “very young” and “very old,” better justify the rationale for excluding allergic contact dermatitis and food allergy as outcomes of interest, and provide the rationale for excluding animal models of “the development of immunological or allergy” outcomes (unless such studies do not exist or are inadequate).

EPA Response to Tier 2 Suggested Revision 4.13: EPA implemented the following five decisions in the revised assessment in response to the five main suggestions above:

1. EPA does not include studies in the evaluation of asthma, asthma symptoms, and asthma control in children younger than 5 years of age or in adults older than 75 years of age. This is because the specificity of symptoms is reduced in the very young (i.e., <5 years) since wheezing can occur with respiratory infections in infants and young children. Specificity is also reduced at older ages (i.e., >75 years) because of the similarities in symptoms and medication use for chronic obstructive pulmonary disease, which occurs in the elderly, and asthma (Taffet et al., 2014; Abramson et al., 2014). Studies examining wheezing or other related symptoms in infants and children < 5 years of age were evaluated within a separate category of “lower respiratory tract conditions in infants and toddlers.” Raaschou-Nielsen et al. (2010) Roda et al. (2011) Rumchev et al. (2002). Li et al. (2019) Yu et al. (2017). However, studies of asthma or asthma symptoms that included ages 3–4 within a larger cohort of older children were included if the proportion of the study group in the age range was likely to be relatively small (e.g., if the mean age was > 5 years); similarly if the age range extended over 75 years the study was included in the asthma evaluation if the mean age was younger, e.g. < 65 years.
2. EPA has replaced the terms “very young” and “very old” with specific age ranges.
3. Allergic contact dermatitis is excluded as an outcome because it is a well-established effect from dermal exposure, and the effects of dermal exposure are not a focus of this review. In contrast, eczema is not an effect of dermal exposure to an allergen but can be triggered by reactions to respiratory and other types of allergens (as well as by other factors); therefore, eczema, but not allergic contact dermatitis, is included as an outcome.
4. Unlike eczema that can be triggered by reactions to respiratory and other types of allergens (as well as other factors), food allergies do not result from exposure to respiratory allergens or other inhaled substances. Because this assessment focuses on inhalation exposures only, food allergies are excluded from consideration.
5. There are currently no universally accepted animal models applicable to humans for determining dose-response relationships or the potency of low molecular weight chemicals to induce allergic symptoms via the inhalation route (IPCS, 2012). Most of the experimental animal formaldehyde studies that are relevant to interpreting these respiratory immune-mediated conditions used the ovalbumin (OVA) murine model, the best studied animal model of asthma. However, the OVA mouse model has several limitations relative to human data for hazard characterization [for details, see immune-mediated conditions synthesis]. Because of these limitations, EPA concluded for this assessment that the OVA model was more appropriate for examining mechanistic questions in support of hazard identification, based in part on the reasonably large number of well-conducted human studies on these endpoints.

##### Related Public Comments

No related public comments were submitted.

#### Study Evaluation

##### Peer Review Findings and Comments

- Finding (6): The outcome-specific criteria used to evaluate human studies were generally appropriate and in line with expert recommendations. However, EPA’s approach appears to contradict the expert panel’s advice that children’s allergic symptoms are more liable to misdiagnosis than those of adults, particularly for asthma in infants and young children.
- Tier 2 Suggested Revision (Recommendation 4.14): EPA should include a specific statement on the age at which asthma diagnosis is considered valid to justify the age exclusions for young children, as well as the category of “the elderly”.
  ○ Related committee comments (Appendix E): “EPA’s approach appears to contradict the expert panel’s advice for asthma. Several studies in infants and young children (<3 years) are examined (p. 1-17 and Table 1-20), where the EPA considers diagnoses in young children to likely be exacerbations of respiratory tract infections rather than representing a true “asthma” phenotype.”

EPA Response to Tier 2 Suggested Revision 4.14: Because of the reduced specificity of symptoms in the very young (<5 years of age) and in the elderly (> 75 years of age), an asthma diagnosis is only considered valid for people who are 5 to 75 years old. Relevant text in the supplemental material that states that the eligible population for asthma is now “humans, age ≥4 years” has been revised to “humans who are 5 to 75 years old.” As noted above, however, studies that included a small proportion of children < 5 are included. This change in definition had no impact on decisions related to dose-response analysis (i.e., the studies selected, the PODs derived, the uncertainties applied, or the values selected as cRfCs, osRfCs, or the RfC).

- Un-Tiered Committee Comment on specific study confidence determinations (Appendix E):
  ○ “Annesi-Maesano (2012) is rated high confidence, despite the vague description of the outcome in Table 1-12. EPA needs to indicate whether this study used an appropriate questionnaire, which would support the high confidence rating.”
  ○ “The study by Smedje and Norback (2001) is rated as low confidence in Table 1-12, page 1-91, contradictory to the text on pages 1-81 and 1-83, which states it is medium. This discrepancy needs to be rectified. The low confidence rating is justified by the large proportion of exposures below the limit of detection, and possible information bias and confounding; however, the “alternative evaluation” of medium confidence features strongly in recommendations and the confidence judgment needs to be consistent throughout the document to avoid confusion…”.
  ○ “It would be helpful to check all the reference table confidence statements with their citations in the text of the documents. Additionally, the tabulated data in the main document need to be checked for consistency with the longer descriptions located in Appendix A.5.4 regarding confidence judgments.”

EPA Response to Un-tiered Committee Comment:

- The questionnaire used in Annesi-Maesano (2012) was the ISAAC questionnaire, which had been identified by the experts consulted by EPA to be a validated, high quality tool. This detail had been included in the Appendix table summarizing the Annesi-Maesano (2012) methods. EPA has added this detail to the table in the Synthesis and Integration in Section 3.2.3 of the revised Toxicological Review.
- EPA considered Smedje and Norback (2001) to be a low confidence study, and it was not used to form conclusions regarding allergy and asthma risk. However, because it was one of only two studies that presented data on effect modification by atopy status, EPA had included it in its discussion of that issue. To avoid confusion, we have removed the discussion of this study from that section. Regarding the confidence classification, a low confidence rating because has been retained because although the study is prospective, there were only two exposure measurements taken, each 1 day (4 hours) over a 4-year period, and 2/3 of the students had left the school more than a year before the health assessment, which further increases the uncertainty regarding the relevance of the exposure measure.
- The details and confidence rating in the study evaluation table (Appendix B.3.4) and the main text and tables (Section 3.2.3) of the revised assessment have been checked for consistency.

##### Related Public Comments

No related public comments were submitted.

#### Evidence Synthesis and Synthesis Judgments

##### Peer Review Findings and Comments

- Finding (7): While EPA accorded some studies of acute exposures high confidence, those studies were not deemed generalizable to other populations (p. 1-114) because of brief exposures not relevant to the chronic-exposure scenario. A short and useful section (p. 1- 122) considers effect modification by tobacco smoke, family history of atopy, and known atopy status.
- Finding (8): EPA’s use of animal data and the resulting synthesis judgments are appropriate, described thoroughly, and consistent with EPA’s state-of-practice methods. The relative risk size of 1.2 for exposures of around 0.04–0.06 mg/m3 is small, but these conditions are common, making this an important outcome. A specific study (Matsunaga, 2008) suggests higher risks, including a two-fold higher risk for eczema, and a three-fold higher risk for allergy-like symptoms from a childhood classroom study that is helpful for determining a POD.
- Finding (9): EPA provides a properly nuanced discussion of the complex MOA for immune-related conditions and identifies many gaps in knowledge, consistent with its state-of-practice methods.
  ○ Related committee comments: “These immune mechanisms are complex and largely beyond the scope of the 2022 Draft.”

##### Related Public Comments

No related public comments were submitted.

#### Overall Conclusions About the Hazard Descriptor

##### Peer Review Findings and Comments

- Finding (10): EPA’s hazard determination judgments are appropriate given the scientific evidence described and are consistent with EPA’s state-of-practice methods.

##### Related Public Comments

- Public Comment (American Chemistry Council): “EPA’s integration of evidence is overly simplistic. Asthma is widely recognized as a heterogeneous group of diseases based on clinical features, physiological characteristics, and varying outcomes ranging from mild to severe. Variation in response to different asthma treatments also suggests that there are multiple mechanisms and pathways that are relevant to the development and exacerbation of asthma. It is not a single disease entity. EPA does not adequately address potential differences in asthma phenotypes that likely represent different underlying biological mechanisms for asthma development. EPA does not describe how the postulated mechanistic pathways are potentially related to different asthma phenotypes. There is a large body of ongoing research focused on improving the understanding of the specific biological mechanisms (or endotypes) that are associated with phenotypes (for example, see Akar-Gibril et al. 2020; Berdine et al. 2020; Carr et al. 2018; Kuruvilla et al. 2019; Kaur and Chupp 2019; Conrad et al. 2021; Schoettler and Strek, 2020; McDowell and Heaney 2020; Lötvall et al. 2011; Wenzel et al. 2012). As a result of differences in phenotypes and endotypes, there are likely different mechanisms (and different modes of action) by which formaldehyde could potentially increase risk. At the very least, the evidence related to potential mode of action should be synthesized separately for occupational asthma (a phenotype that is generally not related to atopic or allergic asthma). Differences in potential mechanisms and the pathogenesis for early onset/atopic asthma versus early onset/non-atopic asthma could also be described (even if these groups cannot be distinguished in the existing epidemiologic studies). Collectively, these differences, which are not related to differences in exposure concentrations, potentially explain inconsistencies in results.”
  “Two studies were selected to derive a point of departure (POD) for current asthma (Annesi-Maesano et al. 2012; Krzyzanowski et al. 1990); however, neither study showed clear associations between current asthma and formaldehyde exposure…Two studies were selected to derive a POD for poorly controlled asthma (Dannemiller et al. 2013) and Venn et al. (2003). These studies only reported correlations between formaldehyde concentrations and poorly controlled asthma. Both studies were cross-sectional studies that relied on response to questionnaires for the identification of poorly controlled asthma. Neither study controlled for potential confounding by indoor allergens that trigger asthma.”
  “EPA’s misrepresentation of the two studies (Krzyzanowski et al., 1990; Annesi-Maesano et al., 2012) it relied on to derive a POD cannot be ignored. EPA’s bias against the chemical to even use a negative study in support of an association does not represent the best available science.”
  “Not only did EPA ignore the two relevant publications by Drs. Golden and Holm, the 2022 Draft Assessment also ignored evidence on the key substances [acrolein] that are considered causally related to asthma. In doing so, the 2022 Draft Assessment presents conclusions that are at complete odds with NASEM (2000) (an authoritative review for the endpoint of asthma) and Kanchongkittiphon et al. (2015) (a comprehensive update involving 69 additional studies focused on indoor environmental exposures and exacerbation of asthma), both of which demonstrated a practical weight of evidence approach…EPA must therefore revise the 2022 Draft Assessment to include a practical Weight of the Evidence evaluation on asthma using the best available science and must account for the contributing role of acrolein.”
  “The revised assessment does not provide clear criteria for evaluating evidence on asthma and provides insufficient support for the classification of formaldehyde as a asthmatogen. The Draft Assessment then calculates several RfCs based on asthma effects (Tale 2-10) without addressing the fundamental issues raised during the NAS (2011) review.”
  “The 2022 Draft Assessment also appears to contain errors in the text:
  ○ The 2022 Draft Assessment states that the EPA conducted a meta-analysis to calculate a summary effect estimate for similar results; there is no further information, and no summary effect estimates are reported.
  ○ Figure 1-11, Panel C: Effect Modification of Prevalence of Current Asthma in Children by Atopy Status) shows increased risks (odds ratios > 3.0) for both atopic and non-atopic asthma in the highest exposed group (>0.06 mg/m3, which also appears to be mislabeled as μg/m3). These odds ratios do not match the results presented in Annesi-Maesano et al (2012). Annessi-Maesano et al. (2012) reported odds ratios of 0.96 and 0.82 for the prevalence of current asthma in the highest exposed group for atopic children and nonatopic children, respectively.” [Please see docket for details and supporting information.]

EPA Response: EPA has retained the same hazard conclusions regarding allergic conditions and prevalence of current asthma or control of asthma symptoms in the revised assessment. These hazard conclusions were supported by the NASEM peer review panel. The studies identified by the commenter that were advanced for POD derivation were Krzyzanowski et al., 1990; Annesi-Maesano et al., 2012; and Venn et al., 2003, noting that Dannemiller et al., 2013 is not advanced for POD derivation. These high (Annesi-Maesano and Venn) or medium (Krzyzanowski, due primarily to small numbers of asthma cases, which is a limitation expected to bias results towards the null) confidence studies are thoroughly reviewed in the assessment, with formal study evaluations documented in Appendix B.3.4, synthesis of their strengths and uncertainties in Section 3.2.3, and re-evaluation of their reliability specifically for use in dose-response in Sections 5.1.1 through 5.1.4.

It is important to emphasize that well-conducted studies with a cross-sectional design can address causation, including the temporality concern raised by the commenter above (see Section 2.3 of the Toxicological Review). This is the case if the study’s measurement(s) of exposure address the etiologically relevant time-period for the outcome under review. Additional discussion and explanation on this well-established epidemiological principle has been added to Sections 2 and 3 of the Toxicological Review. The IRIS assessment paid significant attention to the exposure measurement design and quality during study evaluation. This was discussed in Section 2 and detailed in Appendix B.3 in the public comment/external peer review draft, the final assessment now includes an expanded discussion and rationale on this point in Section 2. Namely, through the extensive analyses of the available epidemiology studies meeting the PECO criteria as well as numerous supplemental resources, the assessment focuses on epidemiological studies with measures of formaldehyde exposure of 5–7 days or more as a high quality exposure assessment representative of exposure levels over the preceding weeks and months. Studies such as Krzyzanowski et al. (1990) with the additional attribute of including formaldehyde measures across multiple seasons provides additional confidence in the interpretation of the measures as representing longer term past exposures. These measurements reflecting long-term, ongoing formaldehyde exposure levels are most useful in developing the chronic RfC and IUR. Exposure assessments of longer duration and in multiple periods provide more precise estimates of longer-term exposure and there is greater confidence in PODs based on them.

The strengths of the study by Krzyzanowski et al. (1990) in this regard have been elaborated in response to a prior comment in Appendix F.3.3. For Annesi-Maesano et al. (2012) and Venn et al. (2003), the assessment now includes a more visible discussion and explanation of the expert panel consultations on allergic conditions and asthma that previously were primarily discussed in the Appendices (mentions and callouts have now been added to Sections 2.3, 3.2.3, and 3.2.4, with a few related notes added to Section 5.1). The two expert panels were each comprised of five international experts convened through an external contractor and vetted for potential COI to consult to EPA on the design, analysis, and interpretation of observational studies of allergic conditions and, separately, asthma. These expert panel consultations were initiated by EPA to provide more in-depth subject matter expertise on immune-mediated conditions. Most observational studies on these outcomes were cross-sectional with concurrent assessment of exposure and of symptoms over a preceding period ranging from 4 weeks to 12 months. For allergies, advice from the five-member expert panel on allergic conditions led to the identification of cross-sectional designs using questionnaires for rhinitis or rhinoconjunctivitis as an adequate basis for case ascertainment in studies in Europe and the United States; in studies in other areas (i.e., areas that have not been included in the International Study of Arthritis and Allergies in Children: ISAAC), specific mention of validation of the questionnaire was needed to receive a high confidence rating. Although the specificity of questions pertaining to rhinitis may be lower than the specificity of questions pertaining to rhinoconjunctivitis (see Kim et al., 2012, HERO ID 2333960), based on the expert feedback received, this difference was interpreted as insufficient to conclude that the rhinitis questions should be viewed with lower confidence. For asthma, again based on consultation with the expert panel, the questionnaire-based approaches used in the available studies were interpreted to have an adequate level of specificity and positive predictive value for use in etiologic research (see Burney et al., 1989, HERO ID 2342689; Jenkins et al., 1996, HERO ID 2919120; and Ravault et al., 2001, HERO ID 2138435) that focuses on the occurrence of episodes of asthma, as opposed to the first occurrence of asthma. As described in the assessment (Section 3.2.3), the design of the study by Venn et al. (2003), a nested case-control study that included a 4-week symptom diary for assessment of asthma control among cases is particularly powerful for the purposes of hazard and dose response assessment. The reliability of the exposure measures in these studies to represent average formaldehyde concentrations over, in the case of Annesi-Maesano (2012), the previous 12 months, and in the case of Venn et al. (2003), the 4 weeks subsequent to the exposure assessment, is discussed in the assessment methods (Section 2.3.1) and evidence synthesis (Section 3.2.3); namely, the sampling periods were considered and justified as reflective of usual average formaldehyde exposure levels experienced by the occupants.

Quantitative use of a NOAEL is an example of a POD that can be based on a study that does not show an effect for a hazard identified based on the available evidence base as a whole. This is a foundational practice in risk assessment. Section 3.2.3 demonstrates, across multiple well-conducted studies, that very low formaldehyde exposures are unlikely to affect the prevalence of current asthma. The evidence synthesis also documents that the exposure levels in Annessi-Maesano were reliably measured and not far below the levels shown to be related to increases in the prevalence of current asthma in the multiple other well-conducted studies used to support the hazard judgment. Thus, use of the NOAEL from Annesi-Maesano et al. to approximate a level below which effects on this outcome are unlikely to occur is reasonable, appropriate, and consistent with EPA’s BMD technical guidance.

For the study by Venn et al., the synthesis text in Section 3.2.3 describes that Venn assessed the potential effects of indoor allergens and did not find that evidence of an adverse effect of NO_2_ or VOCs other than formaldehyde on children’s respiratory health and thus there was no evidence that these indoor allergens were confounders of the observed association between formaldehyde and prevalence of current asthma or control of asthma symptoms. Section 3.2.3 also describes that Venn was a stronger study for this effect than the study by Dannemiller et al. Section 5.1.1 documents the decision and rationale for not advancing Dannemiller et al. to POD derivation.

Overall, the results from these studies were determined to be reliable and robust for use in dose-response analysis. The details of the study results pointed out as potential errors by the commenter have been reviewed and corrected as needed.

- Public Comment (American Forest and Paper Association): “…For the endpoint of asthma there is an authoritative review (NAS 2000) and a comprehensive update (Kanchongkittiphon et al. 2015) involving 69 additional studies focused on indoor environmental exposures and exacerbation of asthma…Having ignored these two relevant and knowledgeable publications, EPA has ignored evidence on the key substances that are considered causally related to asthma. In doing so, the Review presents conclusions that are at complete odds with NAS and Kanchongkittiphon, both of which demonstrated a practical Weight of the Evidence approach…Importantly, EPA provides a review of a subset of the relevant literature instead of a full Weight of the Evidence evaluation on asthma and allergy, when compared to the two reviews mentioned above and reaches a very different conclusion on the role of FA and asthma. EPA concludes that the “evidence indicates” a role of FA with “allergic conditions and current asthma symptoms or degree of asthma control” while the National Academy of Sciences and Kanchongkittiphon et al. (2015) find only limited or suggestive evidence of an association between FA exposure and exacerbations of asthma…Due to its incomplete review of the literature, this Review does not raise to the level of “Weight of the Evidence” using the “Best Available Science” as required by the Lautenberg amendments to the Toxic Substances Control Act (TSCA) (2016). As TSCA will rely on the Review to inform the Risk Evaluation we feel it should be required that EPA conduct a suitable review at this stage in the TSCA Risk Evaluation process. We also urge EPA to revise the document to reflect appropriately the conclusions of the current literature. Of note, the evidence provided in a recent paper (Golden and Holm 2017) that was not cited or integrated into the Review supplies a roadmap of why unrecognized exposure to acrolein is an important confounding factor in many indoor air-related studies focused on FA.”
  “The above noted substances [acrolein] potentially present in indoor air that can exacerbate childhood asthma, many with different levels of certainty, present a substantial challenge with respect to designing and interpreting studies. The discovery that acrolein, an aldehyde that is 200 times more potent as a sensory irritant than FA (Fowles and Dybing 2003) and ubiquitous in indoor air, was significantly associated with asthma, whereas FA was not (Annesi-Maesano et al. 2012). Since it is plausible that FA has served as an unrecognized proxy for acrolein in studies conducted to date, our review (Golden & Holm, 2017) summarizes the well-established dose–response aspects of FA-induced irritation and its potential to exacerbate asthma symptoms. This is followed by a discussion of the available data on acrolein in sufficient detail to document its likely role in exacerbating asthma due to its irritant properties. The implications of acrolein as a previously unrecognized confounder are that indoor air studies, which report associations between FA and childhood asthma, should be interpreted with caution unless/until potential contributions and/or associations with acrolein are also considered. Even Annesi-Maesano et al, 2012, who EPA uses their data to provide a POD for “current asthma prevalence” stated, “Although small, the significant correlations between EIA and PM2.5 and acrolein represent an important message for public health as between 40% and 90% of people with asthma usually have EIA and could be at even higher risk when exposed to air pollution.” In addition, as noted by Leikauf (2002) due to ever-increasing acrolein emissions into the environment, acrolein as a direct irritant may increasingly become a health hazard in individuals with respiratory diseases such as asthma.”
  “Acrolein sources in indoor air are similar to FA…Therefore, it is reasonable to conclude that there is a sound exposure-based rationale for better understanding the potential health impacts of acrolein, particularly as they might relate to sensory irritation and asthma. EPA must incorporate this rational information into their Review.”
  “It is well documented (i.e., Garrett et al., 1998, 1999; Rumchev et al., 2002, 2004) that other substances in indoor air (e.g., VOCs and fungal spores) can cause and/ or exacerbate respiratory symptoms quite apart from FA. Consequently, it is likely inappropriate to conclude that the results reported by Krzyzanowski et al. (1990) can be unequivocally attributed to FA alone in indoor air. EPA has used this study published 32 years ago as “eligible for POD derivation for current asthma prevalence.” Findings of this study (i.e., Peak Expiratory Flow Rate or PEFRs) are questionable in view of the low levels of FA found in the homes and at odds with controlled human studies where FA was the only variable (e.g., Lang et al., 2009). In addition, as in most studies of this kind, the lack of measurements of allergens or other chemical agents that may have been present in indoor air and possibly contributed to reported symptoms is a major confounder. Although the authors did report greater changes in PEFR in children than in adults, the use of this measure does not confirm the presence or absence of asthma or bronchitis or that FA (or something else) was responsible for this finding. This is the only study suggesting differential effects in children versus adults, hardly a convincing basis for concluding that children are more sensitive to FA.”
  “EPA also states in Krzyzanowski et al. (1990), (a study used by EPA to develop a POD for “current asthma prevalence”) that an “increased prevalence of current asthma was seen in the highest exposure group in a categorical analysis.” It is unclear what data EPA are relying on in making this statement. However, as noted in Table 4 of this paper there are three exposure ranges reported, <40 ppb; 41-60 ppb; >60 ppb. There is no dose response exhibited in the data presented and the prevalence rate for asthma in the highest concentration group for children exposed to FA but not to environmental tobacco smoke was 0. The authors report, “…the prevalence rates of current asthma diagnosed by a doctor were significantly increased in children living in houses with high FA levels in the kitchen, but only in those also exposed to ETS.” (Emphasis added). ETS is considered in the Kanchongkittiphon et al., 2015, review to be causally related to exacerbations of asthma in children. This incomplete presentation of the available data even in the studies EPA relies on is inherent in the Review and shows EPA’s bias in the presentation of data.”
  “EPA stated that Annesi-Maesano et al. (2012), reported that FA was significantly associated with rhinoconjuctivitis at median reported FA levels of 21 ppb. However, these levels at which rhinoconjunctivitis (i.e., eye/nose irritation) occurred appear inconsistent with substantial data on dose–response aspects of FA-induced sensory irritation from controlled human studies reported by others. This endpoint is likely confounded by other causally associated substances in indoor air that were not measured in this study and not considered by EPA. This endpoint should not be considered causally related with FA and the study should not be used to derive a POD.”
  “Importantly, Annesi-Maesano et al. (2012) reported that FA was not associated with asthma in this study. Acrolein was the only exposure significantly associated with both asthma (OR: 1.37, 95% CI: 1.14-1.66) and allergic asthma (OR: 1.41, 95% CI: 1.16-1.73) whereas NO2 was statistically significantly associated with asthma (OR: 1.18, 95% CI: 1.01-1.39). FA was statistically significantly associated only with rhinoconjunctivitis (OR: 1.41, 95% CI: 1.08-1.85) but not with asthma.”
  “Comparing the actual data in the [Annesi-Maesano et al. 2012] paper show that for the high dose of FA there is an increase in rhinoconjunctivitis (1.19), a decrease in asthma in the entire sample population (0.90), a decrease in asthma in atopic children (0.96) and a significant decrease in asthma among non-atopic children (0.82). Yet, EPA has used this study to incorrectly include a FA POD for current asthma prevalence. The use of this study to derive or support a Reference Concentration for FA is not consistent with the Best Available Science.” [Please see docket for details and supporting information.]

EPA Response: As noted in the response above and in the revised assessment, Annesi-Maesano and several other supporting studies were used because they represented a set of studies with no effect for asthma at the low levels of formaldehyde that were present. A separate set of studies at higher levels consistently observed effects, providing support for the identified hazard and evidence of a dose-response across studies (rather than within each study). Confounding was explicitly considered during study evaluation. That documentation has been revised (Appendix B.3.4). Note that Billionnet et al. examined acrolein specifically and it wasn’t associated with asthma in their study. But, more broadly, consistent with the consensus peer review finding, “EPA’s hazard determination judgments are appropriate,” EPA has retained the same hazard conclusions regarding allergic conditions and prevalence of current asthma or control of asthma symptoms in the revised assessment. The NASEM committee did not have any Tier 1 recommendations on this topic and EPA has revised the document to address the committee’s findings and other comments.

#### Dose-Response Evaluation

##### Peer Review Findings and Comments

- Finding (11): EPA’s conclusions and its choice of UFs are consistent with its state-of-practice methods, given the confidence levels and quality of the chosen studies. It is appropriate that asthma control PODs pertain to asthma in children, as no studies of asthma control in adults were of high enough quality.

##### Related Public Comments

No related public comments were submitted.

### F.3.6 Reproductive and Developmental Toxicity

#### Charge Question and Peer Review Comment Summary

##### Charge Question 4a. Female Reproductive or Developmental Toxicity

- The assessment concludes that the evidence indicates that inhalation of formaldehyde likely causes female reproductive or developmental toxicity, given appropriate exposure circumstances. The conclusion for female reproductive or developmental toxicity is supported by evidence in humans, specifically, increases in time-to-pregnancy (TTP) and spontaneous abortion risk; mechanistic evidence explaining such effects without systemic distribution of formaldehyde is lacking.
- A POD from Taskinen et al. (1999), a human study, was ultimately selected to calculate an osRfC of 0.01 mg/m^3^ for TTP. A composite UF_C_ of 10 was applied to address UF_H_ and UF_S_.

##### Charge Question 4b. Male Reproductive Toxicity

- The assessment concludes that the evidence indicates that inhalation of formaldehyde likely causes reproductive toxicity in men, given appropriate exposure circumstances. The conclusion for male reproductive toxicity is supported primarily by coherent evidence of several alterations to the male reproductive system in animals exposed to very high levels of formaldehyde (>6 mg/m^3^), with some corroborative changes in an occupational epidemiological study; although no MOA is available, some relevant mechanistic changes have been observed in well-conducted studies.
- A POD from Özen et al. (2002), a rat study, was ultimately selected to calculate an osRfC of 0.01 mg/m^3^ for testis weight. A composite UF_C_ of 3,000 was applied to address UF_H_, LOAEL (UF_L_), UF_S_, and UF_A_ uncertainties.

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 0 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 12 Consensus Panel Findings (numbered below)

#### Literature Identification

##### Peer Review Findings and Comments

- Finding (1): EPA’s process for literature identification, PECO assessment, and study inclusion/exclusion was generally transparent and in line with EPA’s state-of-practice methods for the female and male reproductive and developmental outcomes. However, search terms related to birth defects and teratology, such as congenital anomalies, were not included in the search.

EPA Response to Finding 1: The PECO criteria (Section 2.2) make it clear that birth defects and malformations were included within the scope of the review. While search terms of “birth defects” or “teratology” or “congenital anomalies” were not specifically used, the broader search terms applied in the assessment encompass such health outcomes.

##### Related Public Comments

No related public comments were submitted.

#### Study Evaluation

##### Peer Review Findings and Comments

- Finding (2): EPA’s outcome-specific criteria for evaluating human studies are consistent with EPA’s state-of-practice methods. A summary of key assessment factors specific to human reproductive and developmental outcomes is not provided.
- Finding (3): For human studies, EPA applied the appropriate general criteria for study quality (e.g., epidemiologic biases), consistent with its state-of-practice methods, as were the conclusions for individual studies (e.g., one medium-confidence study for effects on time to pregnancy and two medium-confidence studies for effects on spontaneous abortion).

EPA Response to Findings 2 and 3: EPA applied evaluation considerations specific to the reproductive and developmental outcomes in the epidemiological studies that met the PECO criteria. These considerations were previously discussed in the appendix in the study evaluation section for developmental and reproductive effects. In the revised assessment, tables of the evaluation criteria have been revised and added to the assessment methods section of the Toxicological Review (Section 2.3). These tables outline the criteria used for evaluating each specific outcomes, including time to pregnancy, spontaneous abortion, and postnatal effects.

- Finding (4): For animal studies, EPA applied the appropriate criteria for study quality (e.g., test substance, dose(s), test animals, evaluation endpoints), consistent with its state-of-practice methods, as were the conclusions for individual studies (e.g., two medium confidence studies and three high-confidence studies for male reproductive effects). Potential updates for two high-confidence studies (Ozen, 2015; Ozen et al., 2002, 2005, 2012) and one medium-confidence study (Sapmaz et al., 2018) are detailed in Appendix E. However, the potential reassignment of these three studies would not affect synthesis judgments and the next assessment steps since all medium- and high-confidence studies were considered in the next steps.
  ○ Related committee comments (Appendix E): “Two high-confidence studies (Ozen, 2012, and Ozen, 2015) could be reassessed based on small sample size (N < 10) for reassignment to medium confidence. One medium-confidence study (Sapmaz, 2018) could be reevaluated for consideration as high confidence because the test article box was flagged gray, when it likely ought to be clear.”

EPA Response to Finding 4: The following decisions were implemented regarding the three studies identified by the peer reviewers:

- Sapmaz et al., 2018: The reviewers are correct that the exposure quality domain was incorrectly shaded and that the conduct of exposure was in fact ‘good’; this has been corrected. However, other notable study limitations remain within the test animals and study design domains that warrant keeping the confidence classification as medium rather than increasing it to high confidence. Thus, a rating of medium confidence was retained for this study in the revised assessment.
- Ozen et al., 2005 [note: not 2015] and Ozen et al., 2002: It is acknowledged that a sample size of 10 or greater is generally preferable for the assays performed in these studies (testes toxicity), with these two studies by Ozen et al. including 6–7 males per exposure group. It is important to note, however, that a lower sample size alone does not necessarily warrant reducing confidence. Upon revisiting these study evaluations in comparison with ratings for other animal toxicity studies, it was determined that the limited nature of the study design (i.e., a narrow focus on a few endpoints) and the other identified limitations, when considered in combination with the smaller sample sizes, do warrant decreasing study confidence from high to medium for these studies. Importantly, the identified limitations would be expected to reduce study sensitivity, or the ability of these studies to identify adverse effects on male reproduction (e.g., the 1996 EPA reproductive toxicity guidelines highlight that small sample size typically increases variability and thus reduces the ability to detect effects; this also has implications for dose-response analysis, as discussed in the assessment). In summary, these studies are now identified as medium confidence in the revised assessment.

##### Related Public Comments

No related public comments were submitted.

#### Evidence Synthesis and Synthesis Judgments

##### Peer Review Findings and Comments

- Finding (5): Within EPA’s framework for synthesizing results from human studies and making judgments, the conclusion of moderate evidence for female reproductive or developmental toxicity is justified. However, combining all reproductive and developmental outcomes in a single group is an oversimplification. EPA could consider separating its evidence synthesis section into early and late events.
  ○ Related committee comments: “The justification for combining outcomes was that it would be difficult to distinguish underlying pathogenic events that could yield a delayed recognized pregnancy or fetal loss. Although this rationale may apply generally for delayed time to pregnancy and spontaneous abortion, the broader category of female reproductive and developmental toxicity also encompasses human studies of other “later” developmental outcomes, such as congenital malformations and birthweight.”

EPA Response to Finding 5: EPA did not separate the evidence synthesis section into early and late development events in the revised assessment (see Section 3.3.2). The available human studies were limited by design and they did not allow for such a distinction, e.g., delayed time to pregnancy or spontaneous abortion. The human evidence for events that might more clearly be “later” events was weak and ultimately did not contribute to the assessment conclusions (and the corresponding animal studies were all of low confidence). Without additional health effects evidence or mechanistic understanding about whether the different events are unlikely to be linked, it was not considered appropriate to attempt to draw separate judgments.

- Finding (6): The conclusion of indeterminate evidence for developmental toxicity and female reproductive toxicity in animals is consistent with EPA’s state-of-practice methods.
- Finding (7): The conclusion of slight evidence for male reproductive toxicity in humans is consistent with EPA’s state-of-practice methods.
- Finding (8): Information provided in the text and tables for animal studies of male reproductive toxicity is inconsistent (see Appendix E).
  ○ Related committee comments (Appendix E): “EPA needs to reconcile information provided in the text and in the tables for animal studies of male reproductive toxicity.”

EPA Response to Finding 8: The specific study details have been reviewed and revised as appropriate. Note that the Assessment Overview, which contained some of these discrepancies, has not been retained in the revised assessment.

##### Related Public Comments

No related public comments were submitted.

#### Overall Conclusions About the Hazard Descriptor

##### Peer Review Findings and Comments

- Finding (9): The conclusion that the evidence indicates that inhalation of formaldehyde likely causes increased risk of developmental or female reproductive toxicity in humans is consistent with EPA’s state-of-practice methods.
- Finding (10): The conclusion that the evidence indicates that inhalation of formaldehyde likely causes increased risk of reproductive toxicity in men is consistent with EPA’s state-of-practice methods.

##### Related Public Comments

- Public Comment (Natural Resources Defense Council): “NRDC supports EPA’s determination that inhalation of formaldehyde “likely causes” female reproductive or developmental toxicity in women – EPA’s conclusion is supported by evidence in humans, including time-to-pregnancy (TTP) and spontaneous abortion risk. As NIEHS noted in its comments, “it is reasonable to conclude that female reproductive toxicity based on TTP (Taskinen et al. 1999) and spontaneous abortion (John et al. 1994, Taskinen 1994, 1999) is supported by epidemiological evidence” (NIEHS p. 6) EPA notes that “mechanistic evidence explaining such effects without systemic distribution of formaldehyde is lacking” (p. 54). However, NIEHS comments noted that, “it has been clearly demonstrated that formaldehyde is metabolized to formic acid” which is demonstrated to impair embryo viability and is linked to adverse developmental outcomes (NIEHS p. 6). NRDC agrees with NIEHS that the addition of this scientific evidence and proposed mechanism would strengthen EPA’s evaluation. NIEHS identified this as a “Tier 1” necessary revision. Nonetheless, NRDC concurs with EPA that mechanistic information is not necessary, and a data gap or the absence of knowledge should not be used as a basis for downgrading the strength of evidence. (p. 40)”

EPA Response: The mechanism proposed by the commenter has not been included in the revised assessment given the assumption that inhaled formaldehyde and its byproducts do not reach systemic tissues. EPA Note: Interagency reviewer (e.g., NIEHS) comments were on a draft prior to revision for public release. Please consult the full interagency review comments in the EPA docket.

- Public Comment (American Chemistry Council): “The best available science does not support EPA’s conclusions regarding formaldehyde and reproductive and developmental effects. The NASEM (2011) Committee stated that EPA did not provide a clear weight of evidence discussion to support its classification for reproductive and developmental toxicity and did not agree with EPA’s conclusions…As discussed further below, EPA maintains a similarly strong conclusion regarding the reproductive and developmental evidence, despite the absence of new supportive sentinel studies published in the last decade or any plausible MOA.”
  “The Draft Assessment incorrectly concludes that ‘evidence indicates’ that inhalation of formaldehyde causes increased risk of reproductive and developmental toxicity, and classifies it as a reproductive and development hazard. This is despite the statement (p. 1-414) that ‘The primary basis for this conclusion is based on bioassays in rodents testing formaldehyde concentrations above 6 mg/m3.’ In drawing this conclusion, the Draft Assessment excludes both toxicokinetic considerations and relative dosimetry. This is in direct opposition to Globally Harmonized Classification and Labeling (GHS) guidance as well as EPA guidance on evaluating reproductive and developmental toxicity. First, inhaled formaldehyde is not distributed systemically, thus, it does not affect normal formaldehyde concentrations in reproductive or developmental organs/systems, so it cannot be a direct hazard. Secondly, any reproductive effects were only observed under conditions of high toxicity in the dams, which does not trigger a Hazard Classification for reproductive effects, according to EPA guidelines or GHS. As such, it must not be classified as presenting a reproductive and developmental hazard.” [Please see docket for details and supporting information.]

EPA Response: To clarify, only the conclusion about male reproductive toxicity is based on studies in rodents using high formaldehyde exposure levels. The conclusion that the evidence indicates that formaldehyde exposure is likely to cause female reproductive and developmental effects is based on studies in human workers (see Section 3.3.2). While it is unknown how inhaled formaldehyde may cause these effects without systemic distribution, EPA guidelines do not require such understanding to draw hazard conclusions.

The consideration of confounding effects due to possible overt toxicity in the rodent studies examining male reproductive effects has been revised. In particular, confidence in the candidate RfC based on decreased serum testosterone is now decreased due to the revised interpretation that the responses in the selected study could be amplified due to indirect systemic toxicity (see Section 5.1). However, the remaining key decisions on male reproductive toxicity have been retained.

Overall, consistent with the consensus peer review findings, EPA has retained the same hazard conclusions regarding reproductive and developmental toxicity in the revised assessment. The NASEM committee did not have any Tier 1 recommendations on this topic and EPA has revised the document to address the committee’s findings and other comments.

#### Dose-Response Evaluation

##### Peer Review Findings and Comments

- Finding (11): The rationale for study selection, the POD determination, uncertainty factors, and cRfC derivation, including confidence levels, were consistent with EPA’s state-of-practice methods.
  ○ Related committee comments (Appendix E): “Regarding reproductive and developmental toxicity, EPA needs to double check the publication year for references in Tables 30 and 31. The testes endpoint is likely incorrectly citing, linking to Ozen (2005) when it ought to be Ozen (2002). For animal male reproductive toxicity studies, Ozen (2002) was appropriately considered to be the stronger of the two studies and was therefore used to derive the RfC.”

EPA Response to Finding 11: Tables 30 and 31 of the Assessment Overview in the external review draft did indeed incorrectly cite the 2005 study by Ozen et al. for both sets of male reproductive endpoints considered for dose-response analyses. The Assessment Overview has not been retained in the revised assessment. The revised Toxicological Review correctly cites Ozen (2002) for the testes endpoint and Ozen (2005) for the testosterone endpoint, with the 2002 result considered to be the stronger of the two and that used to derive the candidate toxicity value for male reproductive toxicity (Section 5.1).

- Finding (12): The rationale for exclusion of studies from the dose-response assessment is consistent with EPA’s state-of-practice methods and includes analysis of pooled tissues, short exposure duration, single exposure level, and nonpreferred endpoint assessment.

##### Related Public Comments

- Public Comment (ToxStrategies): “The U.S. EPA’s hypothesize MOA for male reproductive effects misses a critical alternative explanation. Modeling the serum testosterone data from Ozen et al. (2005) resulted in good fitting models with a BMDL_1SD_ value of 0.21 mg/m^3^ in agreement with U.S. EPA (data not shown). Interestingly, this POD is similar to that derived for bodyweight gain changes and testes (see above). A very quick literature search reveals that food restriction affects testes weight and serum testosterone levels in rats (Rehm et al. 2008). If the bodyweight gain changes reported in Ozen et al. (2002) were due to reduced feed intake, then the changes in testes weight and serum testosterone might be related to changes in bodyweight as opposed to formaldehyde toxicity per se. Notably, these effects all occur at about the same concentration—a possible indicator that they are in fact related to one another. This hypothesis seems as likely, if not more likely, than U.S. EPA’s hypotheses about indirect mechanisms like inflammation, oxidative stress, and neuroendocrine disruption (see Section 1.3.2 of the Toxicological Review). That the linkage between feed intake and these same markers of toxicity are not even considered by EPA is problematic. Notably, the Ozen et al. (2002) study that EPA scored as high makes no mention of feed or water consumption despite the significant decreases in bodyweight gain. This calls into question the overall thoroughness and quality of this study.”

EPA Response: The possible indirect effects of reduced food and water consumption (and presumably decreased body weight) on serum testosterone measurements by Ozen et al. (2005), was highlighted as an uncertainty in the revised assessment. The study authors indicate an effect of exposure on food and water consumption, but do not report the specific magnitude of these effects, or possible effects on body weight, for comparative purposes in interpreting the serum testosterone decreases. In the revised assessment, this uncertainty is now highlighted in the study evaluation, evidence synthesis, MOA, and dose-response sections on this study (the latter contributing to a lower level of confidence in the candidate toxicity value based on this finding; see Section 5.1). However, these revisions did not affect any key assessment decisions or conclusions.

Separately, after additional consideration, the observation of reduced body weight gain (note: food intake was not specifically measured in this study) after formaldehyde exposure continues to be interpreted as not affecting EPA’s interpretations regarding potential effects on testes weight (Ozen et al., 2002). As noted in the assessment, in EPA guidelines, and in the study cited by the commenter above (Rehm et al., 2008), toxicity to the testes (e.g., decreased testes weight) is generally independent from effects on body weight leading to a preference outlined in the assessment for absolute testes weight measures. In fact, in the cited study (Rehm et al., 2008), food restriction-induced effects on body weight of nearly 30% (i.e., larger than the body weight % change at 12.3 mg/m^3^ in Ozen et al., 2002) had no effect on absolute testes weights. A limitation noted for Ozen et al. (2002) is that only relative, not absolute, testes weights were reported. However, because relative weight reflects the ratio of the organ weight to body weight, a decrease in body weight without a parallel decrease in the organ weight would increase the relative weight; the primary concern with relative testes weight is that the body weight decrease (artificially increasing the relative organ weight result) would mask (reduce the magnitude) of the specific formaldehyde-induced decreases. Thus, the decreases in relative testes weight in Ozen et al. (2002) are considered real and are likely an underestimate of the true effect magnitude in that study, were absolute testes weights available. The discussion of Ozen et al. (2002) was not changed.

- Public Comment (American Chemistry Council): “Neurotoxicity and reproductive and developmental toxicity studies used for dose-response and/or hazard classification did not meet the criteria in USEPA guidance for the confidence ratings proposed in the Draft Assessment yet were advanced (sometimes even all of the way to RfC development)… The Ozen et al. (2002) and Ozen et al. (2005) subchronic rat studies were rated ‘high confidence’ studies and used to derive osRfCs for potential male reproductive toxicity in the Draft Assessment. Both studies had numerous deficiencies that would lead to a grade of ‘uninformative’ and thus not used for either hazard classification or dose-response assessment, as follows.” [Please see docket for details and supporting information.]

EPA Response: The male reproductive toxicity studies highlighted by the commenter were evaluated and synthesized in accordance with the criteria in Section 2.3 and EPA’s guidelines. While study limitations that affect the utility of these studies for dose-response analysis were identified (and which are highlighted in the assessment and lead to low confidence in the derived values), these limitations did not affect the study evaluation ratings. However, it is noted that these studies were reevaluated based on peer input and now are classified as medium rather than high confidence (see documentation in Appendix B.3). EPA Note: neurotoxicity was not identified as a hazard and no neurotoxicity studies were advanced for dose-response analysis in either the external review draft assessment or the revised assessment.

### F.3.7 Nervous System Effects

#### Charge Question and Peer Review Comment Summary

##### Charge Question 4c. Nervous System Toxicity

- While many studies reporting evidence of potential neurotoxic effects were available, due to limitations identified in the database (e.g., poor methodology, lack of consistency), it was ultimately determined that the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might pose a human nervous system hazard. This judgment was separately arrived at for three different manifestations of potential neurotoxicity, namely developmental neurotoxicity, altered neurobehavior, and an increased incidence of, or mortality from, the motor neuron disease amyotrophic lateral sclerosis. The evidence integration narrative emphasizes that additional study is warranted.
- The available data on potential nervous system effects were considered insufficient for developing quantitative toxicity estimates.

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 0 Tier 2 Suggested Revisions
- 1 Tier 3 Future Consideration
- 9 Consensus Panel Findings (numbered below)

#### Literature Identification

##### Peer Review Findings and Comments

- Finding (1): The process for literature identification and inclusion/exclusion criteria for the review of nervous system effects was transparent.
  ○ Related committee comments on literature identification (Appendix E): “Regarding the nervous system, Figure A-35 of the Supplemental Information indicates that 40 human studies were considered, but only 12 are described in the Main Assessment in (Tables 1-44 and 1-45), and 15 were included in the Appendices (Tables A-84 and A-85). The narrative indicates that studies that were evaluated as not informative were excluded from these tables; however, both the Kilburn (2000) and Schenker et al. (1982) studies are described despite their overall confidence evaluation of not informative. Thus, it is not clear why these studies were included in the table. Clear reasoning for exclusion from tables need to be provided or the literature described in Tables A-84 and A-85 need to be updated to be consistent with the information provided at the end of Figure A-35.”
    “Table A-84 incorrectly describes the sample for the Bellavia et al. (2021) paper as “cancer cases”; however, they were amyotrophic lateral sclerosis (ALS) studies from registry data. The job exposure matrices (JEMs) for this study was developed for a previous cancer study; ALS cases were identified through Danish medical records without consideration of cancer status. The details in Table A-84 need to be reviewed for accuracy, and minor typographical errors need to be addressed.”

EPA Response to Finding 1: The clarifications noted by the committee have been incorporated.

- Finding (2): EPA elected to exclude headache as a human health outcome for evaluation because of the subjectivity of outcome reporting (Appendix A, Table A-83). Considering that other endpoints included in this assessment, such as sensory irritation, depend on subjective self-reporting, excluding headache based on this criterion is inconsistent.
- Tier 3 Future Consideration (Recommendation 4.15): EPA should include studies with headache as an outcome to maintain consistency with other health effect categories. Alternatively, a stronger rationale should be provided for exclusion of headache other than its perceived subjectivity. Headache could be combined with other self-reported neurotoxicity outcomes.

EPA Response to Tier 3 Future Consideration 4.15: In addition to being subjectively reported, headaches were typically not rated by severity and were often pooled with non-nervous system-specific complaints (e.g., related to irritation, such as dry eyes). Further, questions remain regarding the specificity of the complaints to nervous system effects, as they could be byproducts of other health symptoms (e.g., irritation-related complaints were frequently correlated). These additional explanatory considerations have been added to the assessment methods. It is also noted that, as was generally not the case for sensory irritation, studies of objective measures of nervous system effects that involved long-term formaldehyde exposures were available, and thus were preferred. Separately, it is noted that in many of the available studies, individuals were included in the study due to complaints about symptoms attributed to exposure to chemicals in the air, and thus these studies would generally involve critical concerns about selection bias. This has been clarified in the revised assessment.

##### Related Public Comments

No related public comments were submitted.

#### Study Evaluation

##### Peer Review Findings and Comments

- Finding (3): Overall, criteria for evaluating human studies were consistent with EPA’s state-of-practice methods. However, it is not clear whether the study quality criteria were applied uniformly across studies.

EPA Response to Finding 3: The study evaluation criteria were reviewed and revised to address each of the evaluation domains assessed in the studies of human exposure. These criteria were cross-checked with the evaluation tables for studies of nervous system effects in the appendix. The review resulted in changing the confidence conclusions for two of the studies based on the criteria for exposure assessment (Bellavia et al., 2021) (medium to low) and other limitations including small number cases (Pinkerton et al., 2013) (high to medium).

- Finding (4): Where explanations are provided for confidence assessments for more recently published literature, EPA gives no details about the basis for confidence decisions for controlled exposure studies in humans (Appendix A, Table A-85).

EPA Response to Finding 4: “Table A-85” (Appendix Table B-50 in the revised assessment) documents the evaluations of the three controlled human exposure studies of neurobehavioral outcomes. Confidence in two of the studies (Bach et al., 1990; Andersen and Molhave, 1983) was low because test batteries were performed during exposure (irritation anticipated to result in distracted responses), an incomplete set of tests were conducted, authors did not report whether subjects or administrators were blinded to exposure, and deficiencies in reporting were noted. Methods were not as limited in the third study (Lang et al., 2008).

- Finding (5): Regarding human studies, study quality criteria (i.e., selection bias, sample size, exposure assessment, and confounding) were consistent with EPA’s state-of-practice methods. However, the reasons for final conclusions on study confidence are not always clear, and there are inconsistencies in the explanations for the confidence ratings. Potential updates to specific studies (e.g., Bellavia et al., 2021; Kilburn, 2000; Pinkerton et al., 2013; Schenker et al., 1982; see also Seals et al., 2017 and Peters et al., 2017) are detailed in Appendix E.
  ○ Related committee comments (Appendix E): The following comments were made:
    ■ “Pinkerton et al. (2013) was rated with high confidence, with a comment of “small number of cases” in reference to 8 ALS deaths. However, other studies with a small number of cases were rated as medium.”
    ■ “Kilburn (2000) and Schenker et al. (1982) were assessed as not informative with comments about limited or no exposure measures. However, it is important to note that two of the included manuscripts used some version of the same set of Danish registry data (Seals et al. [2017] and Bellavia et al. [2020]), both used JEMs derived from the Swedish JEM used in the Peters et al. (2017) manuscript as part of the Nordic Occupation Cancer Study, and each of these JEMs estimate exposure based on previous studies of biological samples, air and dust monitoring, and expert opinion, and are not direct exposure measures. Furthermore, the occupational codes used to determine exposures are not based on job title, but only on tax-recorded industry codes. Therefore, exposure assessment provided in these studies is not significantly better than that provided in the studies ranked with low confidence.”

EPA Response to Finding 5: The study evaluation criteria were reviewed and revised to address each of the evaluation domains assessed in the studies of human exposure (Section 2.3.7 in the revised Toxicological Review). These criteria were cross-checked with the evaluation tables for studies of nervous system effects in Appendix B.3.7. The review resulted in changing the confidence conclusions for two of the studies based on the criteria for exposure assessment (Bellavia et al., 2021) (medium to low) and other limitations including small number cases (Pinkerton et al., 2013) (high to medium). Kilburn (2000) and Schenker et al. (1982) were rated as not informative primarily because of concern that the exposed group was selected on the basis of their exposure to formaldehyde. The selection bias would be expected toward an inflated estimate of risk. Limitations in the other low confidence studies included deficiencies in reporting study methods and results and a lack of information on variation or intensity of exposure (Kilburn et al., 1985b; Kilburn et al., 1987; Kilburn et al., 1989b; Kilburn and Warshaw, 1992). The studies with exposure assessments based on the Nordic Occupation Cancer Study assigned formaldehyde levels to individuals based on industry and occupation codes. The Danish studies used the Danish Pension Fund for occupational histories while the Swedish studies used the national census. While these databases record jobs at the industry/occupation level, the job-exposure-matrix uses monitoring data specific to each country developed by industrial hygienists with expertise in the industries for each country. Exposure misclassification is expected, however this method provides information on the variation in levels and intensity of exposure in the study population. Bellavia et al. (2021) assigned exposure to formaldehyde as “ever” versus “never” and therefore was reclassified as low confidence.

- Finding (6): Regarding animal studies, study quality criteria were consistent with EPA’s state-of-practice methods.

EPA Response to Finding 6: In ensuring consistency in evaluations across studies of a particular type (e.g., in vivo experimental animal studies), three in vivo studies examining mechanistic changes received a revised rating of medium, from high, confidence: Sorg, 2001, 626595, Tsukahara, 2006, 626805, and Hayashi, 2004, 626503

##### Related Public Comments

No related public comments were submitted.

#### Evidence Synthesis and Synthesis Judgments

##### Peer Review Findings and Comments

- Finding (7): With human studies having medium and high confidence for ALS and low or not informative confidence for neurobehavioral outcomes (e.g., memory, mood changes), along with medium confidence for animal studies on developmental neurotoxicity, the basis for the overall evidence judgment is not well articulated.

EPA Response to Finding 6: The three separate evidence integration conclusions regarding the potential for (1) changes in ALS incidence, (2) neurobehavioral alterations, and (3) structural changes in the developing brain across the available human, animal, and mechanistic studies relevant to each are outlined in Section 3.3.1 and summarized separately in the evidence profile tables at the end of that section. This presentation has been revised in the final assessment. As outlined in the methods for evidence synthesis and integration (Sections 2.5 and 2.6), the conclusions are not based on confidence in the individual studies, but rather they are based on the consistency, coherence, and dose-dependence, etc. of the results of the higher confidence studies, alongside additional considerations including the human relevance of the findings in animals and the biological plausibility of the observed effects.

- Finding (8): The 2011 NRC committee found the discussion of the neurogenic MOA in the 2010 Draft Assessment to be vague and speculative. In the 2022 Draft Assessment, EPA provides a much more thorough overview of potential MOAs without speculative conclusions.

##### Related Public Comments

No related public comments were submitted.

#### Overall Conclusions About the Hazard Descriptor

##### Peer Review Findings and Comments

- Finding (9): The conclusion that the evidence suggests but is insufficient to infer significant long-term neurotoxicity from inhaled formaldehyde in humans is consistent with EPA’s state-of-practice methods, given the number of studies with final assessments of confidence in the not informative to low range, and very few being assessed as having medium or high confidence.

##### Related Public Comments

- Public Comment (American Chemistry Council): “The 2022 Draft Assessment stated, ‘Overall, conclusive of a nervous system health hazard in humans exposed to formaldehyde was not identified (i.e., suggestive evidence).’ The finding of ‘suggestive evidence,’ however is at odds with EPA’s acknowledgement of inconclusive evidence. Indeed, a critical review of the available evidence suggests that an ‘inadequate’ descriptor would be more appropriate for this endpoint… Given the lack of data for any postulated MOA and failure to demonstrate consistent effects across any endpoint, an integration judgment of ‘evidence is inadequate’ is more appropriate rather than the proposed ‘suggestive’ integration judgment for nervous system effects.” [Please see docket for details and supporting information.]

EPA Response: Consistent with the consensus NASEM peer review finding (9, above), the conclusion of evidence suggests but is insufficient to infer is retained in the revised assessment. Section 3.3.1 describes the rationale for drawing a judgment of slight evidence of formaldehyde-induced nervous system effects in humans, including the potential for effects on amyotrophic lateral sclerosis disease incidence, neurobehavioral changes, and structural changes in the developing brain. The available studies were limited, and none were advanced for dose-response analysis. The potential for nervous system effects remains an area deserving of additional study.

### F.3.8 Derivation of the RfC

#### Charge Question and Peer Review Comment Summary

##### Charge Question 5. Noncancer RfC

An RfC was selected based on the grouping of osRfCs for sensory irritation, decreased pulmonary function, allergy-related conditions, and increased prevalence of current asthma or decreased degree of asthma control. Please comment on whether the approach and selection of the proposed RfC was clear and scientifically justified, including consideration of other potentially sensitive health effects.

##### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 1 Tier 2 Suggested Revision (multiple parts)
- 1 Tier 3 Future Consideration (multiple parts; note: not numbered in NASEM study report)
- 1 Un-Tiered Committee Comment
- 1 Consensus Panel Finding

#### Peer Review Findings and Comments

- Finding (1): The Main Assessment and Appendices reflected EPA’s efforts to follow its various guidelines and are generally consistent with its 2022 IRIS Handbook. The committee identified concerns with the dose-response approach taken for some studies (e.g., Hanrahan et al., 1984, as detailed in Table 4-3 and footnotes). Other occasional issues concerning consistency and accuracy were sometimes the result of omissions or inadequate documentation. More than a dozen specific examples are detailed in Appendix E, which provides additional suggestions regarding EPA’s consideration of the following studies: Kulle et al. (1987); Andersen and Molhave (1983); Krzyzanowski et al. (1990); Dannemiller et al. (2013); Woutersen et al. (1989); Ozen et al. (2002, 2005); and Kerns et al. (1983). [Note: EPA interpreted the Appendix suggestions on these studies as an unnumbered Tier 2 suggested revision below]
  ○ Relevant committee comments: As noted in Table 4-3 of the consensus study report, “the committee had concerns about EPA’s approach to deriving the POD” for the following three studies: Hanrahan et al., 1984; Kulle et al., 1987; and Andersen and Molhave, 1983. Although suggestions for improvement were noted in several cases, the committee did not note concerns about EPA’s approach to deriving PODs for the remaining studies for which PODs were derived by EPA in the draft assessment.
- Un-tiered Committee Comment on modeling of specific studies (from Appendix E):
  a) Kulle 1987; Andersen and Molhave 1983: “it is uncertain whether a factor of 2 is greater than the true ratio of BMC/BMCL (i.e., whether it is sufficiently large to account for the data dependence)…. [this] appears inconsistent with EPA’s own guidelines and EPA did not provide a justification.”; “[no methods for] conversion of the Likert-scale [Kulle] …to the dichotomous variable used to estimate prevalence.” “… [for the] human studies of Kulle et al. (1987) and Andersen and Molhave (1983), EPA correctly recognized that the same group of volunteers were exposed to multiple concentrations, and the responses from individual volunteers were correlated across different exposure concentrations. EPA’s benchmark dose (BMD) modeling failed to account for such data dependence, and thus likely underestimated the variation of the BMC. EPA subsequently divided the benchmark concentration (BMC) by a factor of 2 to replace the model-based benchmark concentration lower bound (Table 2-2). However, it is uncertain whether a factor of 2 is greater than the true ratio of BMC/BMCL (i.e., whether it is sufficiently large to account for the data dependence). This practice appears inconsistent with EPA’s own guidelines and EPA did not provide a justification.”
  b) Kulle et al., 1987: “Kulle et al. (1987) measured eye irritation using a 4-point Likert scale for none, mild, moderate, and severe, and reported the mean score difference (standard error) between 180 minutes postexposure and baseline. EPA’s dose-response modeling of Kulle et al. (1987) and Andersen and Molhave (1983) was, however, for the fraction of affected (i.e., prevalence of eye irritation). EPA did not provide information in the Main Assessment or Appendices on the conversion of the Likert-scale in Kulle et al. (1987) to the dichotomous variable used to estimate prevalence.”
  c) Krzyzanowski 1990: “For pulmonary function, EPA relied on the linear mixed-effects model results reported by Krzyzanowski and colleagues (1990). The original regression model incorporated whether or not the children had asthma and whether or not the exposure measurements were taken in the morning. EPA’s derivation of the BMCL was based on children without asthma exposed at times other than the morning. This approach was inconsistent with EPA’s state-of-the-practice methods (i.e., using more vulnerable subpopulations for risk estimation). To its credit, however, EPA conducted a sensitivity analysis for children with asthma and morning exposures. The sensitivity analysis, however, was based on BMC, but would more appropriately be based on BMCL. The derivation of a BMCL for children with asthma can be achieved by first determining the standard errors of the combination of regression coefficients associated with the terms of formaldehyde concentration and concentration squared. Note that children with asthma had their own baseline prospective epidemiological risk factor (PERF) (348.09) and the corresponding 10 percent decrease of 34.8. The intercept in equation B-9 is incorrect.”
  d) Krzyzanowski 1990; Dannemiller 2013: “EPA used either a group median (e.g., current asthma, Krzyzanowski et al. [1990]) or a group mean (e.g., atopic eczema, Matsunaga et al. [2008]) as an estimate of lowest observed effect level / no observed effect level (LOAEL/NOAEL) when a range of exposure concentrations was reported within the group. EPA also seemed to have used either an arithmetic mean or a geometric mean to estimate a LOAEL/NOAEL. Dannemiller et al. (2013) reported the geometric mean of 54.0 and 34.4 ppb in the “very poor control” group and “all others” group, respectively. EPA seemed to have designated 34.4 ppb as the NOAEL (0.042 mg/m3, Table 2-4, [footnote e in this table indicating that EPA did not make this decision explicit). (Note that the reference in the last row of Table 2-4 ought to be Dannemiller et al. [2013]). The study of Dannemiller et al. (2013) was dropped from the discussion for cRfC derivation thereafter. EPA did not give reasons for excluding this study. The text starting from page 2-16, line 19, appears corrupted.”
  e) Kerns 1983; Woutersen 1989: “EPA reanalyzed the animal data of Kerns et al. (1983) (Level I of sagittal crosssection I only) and of Woutersen et al. (1989) (anterior, Levels I and II). EPA did not disclose whether it obtained raw data or extracted secondary data from the original report. Multiple models were fit to the datasets, and the one with the smallest Akaike information criterion (AIC) was chosen. Note that AIC is a relative criterion for comparison across models. Alone, AIC does not tell how well a model fits the data… EPA did not report goodness-of-fit tests, a practice inconsistent with the reanalysis of other studies in the Assessment… “osRfC for respiratory pathology was based on Woutersen 1989. Kerns 1983) was incorrectly cited in Table 2-11.
  f) Ozen et al. (2002, 2005: “In the reanalysis of the data from Ozen et al. (2005), EPA stated that (p. B-23, lines 6–8): “If the BMDL estimates were ‘sufficiently close’, that is, differed by at most xx-fold, the model selected was the one that yielded the lowest AIC value. If the BMDL estimates were not sufficiently close, the lowest BMDL was selected as the POD.” This criterion is vague and does not enhance transparency.”
    “In conducting BMD modeling of Ozen et al. (2002) and Ozen et al. (2005), which had three and four distinct concentration levels (including the control), respectively, EPA fit models with three or four parameters, resulting in parameter saturation in the model or failure in model fitting.” [Note: “The various model-based tests for the Ozen et al. (2005) study were labeled as “test 1”, “test 2”, etc. (Table B-17, p. B-29) without explanation.”]

EPA Response to Un-Tiered Committee Comment on study-specific modeling decisions: The following changes were made.

a) The assessment has been revised to select PODs from these studies based on a wider confidence interval (i.e., the 99th as compared to the typical 95th percentile lower bound) rather than the BMC divided by 2. This widened confidence interval provides a means of more transparently approximating the increased variability expected if independent data measurements were available. Perhaps more importantly, it is based on the variability within the experimental data rather than a factor of 2 applied regardless of the underlying data variability. Ultimately, use of the 99^th^ percentile results in PODs from these two studies that are in some cases less than 2-fold below the BMC and in other cases more than 2-fold (almost 4-fold in one instance) below the BMC, depending on the underlying experimental data. The revised PODs remain similar to those in the external review draft (i.e., for the study by Kulle et al., the selected POD is now 0.44 mg/m^3^, as compared to 0.42 mg/m^3^ previously; for the study by Andersen and Molhave, the POD is now 0.12 mg/m^3^, as compared to 0.19 mg/m^3^ previously). The dose-response analysis for these studies is outlined in Appendix D.1.1.
b) The assessment has been revised to model the data from (Kulle et al., 1987; Kulle, 1993) using Categorical Regression analyses (CatReg; https://www.epa.gov/bmds/about-catreg) to more fully explore both the reported severity information as well as the available data for multiple endpoints of sensory irritation. To clarify, the external review draft combined the reported symptoms of mild and moderate severity into an “affected” count (note: the published data on the mean symptom difference or symptom score difference in the 1987 publication were not modeled previously and are not modeled in the revised draft as those findings involved pooled measures across individuals with differing severity and thus are not preferred for modeling without access to the underlying data and score calculations; the modeled data used in the external review draft and the revised assessment are reported in the 1993 reanalysis). The symptoms of differing severity are now more fully considered using CatReg. Overall, the application of CatReg in the revised assessment does not have a large influence on the selected sensory irritation POD from (Kulle et al., 1987; Kulle, 1993), but it does facilitate greater inclusion and combining of the available data. See Appendix D.1.1 for details.
c) EPA attempted to reach the study authors for additional details; however, no additional information was available (see earlier responses). EPA contacted Dr. Krzyzanowski regarding this analysis and notes that there was no main effect for ‘asthma’ in the model and any information on the covariances between the terms was unavailable. These additional attempts are noted in the revised assessment.
d) The reasons for not advancing Dannemiller et al. (2013) and the details related to POD decisions on Krzyzanowski et al. (1990) have been added or clarified, respectively, in the revised assessment.
e) The assessment was revised to state that EPA extracted the data from the Battelle Report and from Woutersen et al. (1989). Overall goodness of fit p-values have been added to the revised Appendix D.1.4. The error for Woutersen was corrected as noted.
f) The fold-change was clarified in the revised assessment to reflect that a 3-fold difference is what is typically used. Regarding parameter saturation, if one runs a n-parameter model on a dataset with n-total dose groups (including controls), there will not remain a degree of freedom left to calculate a goodness-of-fit p-value and BMDS will report N/A. In that case, the model is not further considered for selection. In the revised assessment, the POD derivation for the Ozen studies was re-performed, with decisions made consistent with the committee comments (see Appendix D.1.5).

- Tier 2 Suggested Revision (Recommendation 4.16): EPA should carefully address the following points regarding the derivation of the RfC:
  a) Fully disclose data extracted from original study reports using HERO or other means.
  b) Cite relevant guidance documents regarding the use of a mean versus median and arithmetic mean versus geometric mean to estimate a lowest observed adverse effect level or no observed adverse effect level.
  c) In reanalyzing data from published studies, the use of raw data is preferred. Aggregated data may be used when appropriate. At a minimum, group size, group mean, and a measure of variance (e.g., group standard deviation or standard error of the mean) for each exposure level are needed to capture data variation in a reanalysis of dose-response.
  d) Avoid fitting a dose-response model that has as many parameters as the number of distinct aggregated data points taken from the published literature. Report and consider only models that meet the goodness-of-fit criteria EPA accepts.
  e) To ensure that the resulting benchmark concentration lower bound is not artificially overestimated, better account for within-group variability in the dose-response analysis of Hanrahan et al. (1984) to address limitations arising from reliance on only secondary, aggregated rates per exposure group that were extracted from the plot of the originally fitted model.
    Committee comments related to “e” (from Appendix E): “[The] regression model has artificially narrow standard errors for the model parameters compared with those fitted to the raw data because the model-predicted means failed to reflect the true data variation. As a result, the model-based BMDL (0.09 mg/m3) is biased. Therefore, the use of the cRfC derived from Hanrahan et al. (1984) as the osRfC for sensory irritation needs additional justification.” [Note: In Appendix D, NASEM is able to replicate EPA methods; but recommends combined modeling with Liu 1991 to result in a lower BMC by ~20%]… “EPA extracted 8 distinct model-predicted means, one for each exposure concentration, from the Hanrahan et al. (1984) by reading a plot (Figure 1), and then refitted a logistic regression model with a polynomial of order 3. The resulting logistic regression model has artificially narrow standard errors for the model parameters compared with those fitted to the raw data because the model-predicted means failed to reflect the true data variation. As a result, the model-based BMDL (0.09 mg/m3, Table 2-2) is biased.”
  f) Be more explicit as to how the final RfC was chosen (in Figure 2-2 of the 2022 Draft Assessment and elsewhere).
    Committee comments related to “f” (from Appendix E): “Figure 2-2 displays variability and uncertainty across all osRfCs along three dimensions: confidence, uncertainty, and risk size. The committee found this graphic display to be an effective visual aid. The size of the plot symbol for each osRfC was determined by three factors: the level of the confidence in the study(ies) and health hazard identification; risk estimate(s) (EPA gives slightly greater weight to the risk estimate than other factors); and completeness of evidence database for each health outcome. However, EPA was not explicit about how these factors were weighted.” … “Figure 2-3 is also interesting and informative. It graphically displays the uncertainties within a cRfC as well as variations and uncertainties between cRfCs.” … “EPA presented a detailed discussion of uncertainties and variabilities, and noted that the osRfCs for asthma, pulmonary function, allergies, and sensory irritation were 0.006, 0.007, 0.008, and 0.009 mg/m3, respectively, reflecting the impact of formaldehyde on the respiratory system. EPA proposed the overall RfC of 0.007 mg/m3 but was not explicit about how it was chosen.”

EPA Response to Tier 2 Suggested Revision 4.16: The following revisions were implemented.

a) This documentation has been revisited and revised as appropriate (note: one dataset provided in a memo from CIIT has been added to Appendix D.2.2 in its totality for transparency).
b) EPA’s BMDS technical guidance defines “Central estimate” as the mean or median value. However, EPA has clarified the rationale for individual decisions on POD selection in the revised assessment.
c) This comment is noted and appreciated. Modeling of multiple datasets has been redone.
d) In the revised assessment, models are selected in accordance with this criterion.
e) EPA provides additional analyses building from the recommendation above in the revised assessment (see Appendix D.1.1 on sensory irritation) by combining the dose-response data from Hanrahan et al. (1984) and Liu et al. (1991). Using the data available and building on approaches outlined by the NASEM committee, EPA now estimates a BMCL from the combination of these studies. Concerns about the precision of the estimate remains; however, the value based on the combined studies is judged as more stable and appropriate. Note that, in estimating a BMCL from Hanrahan et al. (1984) alone in the external review draft, EPA used the information on lower confidence bound on the main effect. The lower bound captures information about the standard error and incorporates within-group variability in the dose-response analysis.
f) In the revised assessment, the midpoint of the three highest confidence values (0.006, 0.007, 0.008 mg/m^3^) was selected as the RfC (Section 5.1.5). The supporting rationale was revised. The figure supporting the rationale for selecting the RfC based on the three values has also been revised to be more transparent. Facilitating this transparency, greater resolution of the confidence determinations for each value is now provided, which allows for straightforward, step-wise changes in the size of the shape based on step-wise changes in confidence across the values (e.g., from low to low-medium to medium-low to medium to medium-high, etc.).

- Tier 3 Future Consideration 4.17 [note: not numbered in the NASEM report]:
  a) Handle dose-response modeling of correlated data (e.g., Andersen and Molhave, 1983; Kulle et al., 1987) by standard statistical methods, employing a two-step process that involves first fitting a dose-response model for correlated data using standard statistical methods, and then deriving BMC and BMCL using the fitted model.
  b) Develop methodology that goes beyond a qualitative display of the variability and uncertainty of cRfCs or osRfCs. The current EPA method has limited reproducibility because of the lack of detail. A meta-analysis approach offers a viable option.

EPA Response to Tier 3 Future Consideration 4.17: EPA appreciates these future considerations and the topics have been highlighted to the IRIS Program’s statistical working group for consideration in modeling data from studies in future assessments.

#### Public Comments on the RfC

- Public Comment (ToxStrategies): “It is difficult to verify all the BMD modeling results as Appendix B clearly indicates that the model outputs were run nearly a decade ago in January of 2013, apparently using EPA’s BMD software (BMDS) v1.9. The current version of BMDS is v3.2. U.S. EPA’s BMDS website (https://www.epa.gov/bmds) explicitly states that BMDS 2.7 is no longer supported, and this must also be true for prior versions. It is reasonable to expect that any new U.S. EPA assessment should use the most current (and supported) version of BMDS. The U.S. EPA should re-run all the BMD modeling in the assessment with the latest version of BMDS.
  Curiously, many of the BMD modeling results in this document are expressed in units of mg/kg-d as opposed to mg/m3. This is likely a result of the modeling software not knowing the units, but it is surprising that EPA did not correctly indicate the units. Moreover, all the discussion about BMD models should technically be benchmark concentration (BMC) as these are inhalation concentrations as opposed to oral doses.”
  “U.S. EPA’s benchmark dose modeling of rat respiratory histopathology has several reporting and methodological flaws.”
  “U.S. EPA’s benchmark dose modeling of male reproductive toxicity studies has several potential flaws.” [Please see docket for details and supporting information.]

EPA Response: It is not EPA’s practice to update modeling results because a new version of BMDS software is released (note: most of the BMDS modeling in the Step 4 draft was done using BMDS v2.2). It is also important to emphasize that the few modeling results derived using BMDS were for studies in experimental animals, and the results from the animal studies were not the drivers of the assessment conclusions. However, in the process of reviewing the PODs from these animal studies to address other peer review and public comments, multiple datasets were re-run using BMDS Online (v3.3). For example, the modeling and reporting of the rat respiratory histopathology has been revised. However, the 24-month data cannot be modeled as the incidence (0.01, 0.97, 0.99, 1.0) saturates at the first non-zero dose. Likewise, the modeling of male reproductive toxicity studies was also re-modeled, and several errors, including incorrect units, were corrected.

- Public Comment (American Chemistry Council): “The Draft Assessment does not present explicit rationales for selecting a particular benchmark dose (BMD) or for choosing BMD over a LOAEL/NOAEL approach. In particular it must be clarified when effects are observed at concentrations above the range of saturable metabolism (i.e., 1-2 ppm for formaldehyde), but extrapolated to doses below the range of saturable metabolism.”
  “In Table 2-10 on pages 2-30 and 2-31, NOAELs are not presented and a discussion of the dose levels used in the studies is not provided, in favor of only presenting the POD…In the derivation of the cRfC for male reproductive toxicology from Ozen et al. (2002), a POD of 2.91 is listed, with a combined uncertainty factor of 3,000, to yield a cRfC of 0.001 mg/m3. Without knowledge of the assumptions underlying this calculation, the reader cannot evaluate uncertainty and conservatism in the calculation. The lowest concentration tested in the study was 12 mg/m^3^, which is 12,000 times above the calculated osRfC. This highlights that there is more uncertainty in the extrapolation than presented.
  Additionally, the Draft Assessment states (p. xxii): ‘… higher confidence was placed in the osRfC when the POD was identified close to the range of the observed data.’ However, almost all the RfCs and osRfCs were modeled outside of the range of the observed data which introduces substantial uncertainties, none of which appear to be recognized in the draft assessment.”

EPA Response: The commenter’s statement that almost all the noncancer toxicity values in this assessment were modeled outside of the range of the observed data is incorrect. Most notably, the PODs supporting the RfC are all within the range of the observed data, as are most of the other PODs. This feature of the noncancer evidence base was highlighted in the NASEM peer review report (consider calling out what page in that report). For the minority of PODs that are based on occupational exposure or on animal studies with higher exposure levels, this uncertainty is described. Note also that a reliable BMC-based POD is preferred over NOAEL- or LOAEL-based POD, consistent with EPA guidelines. The revised assessment clarifies the rationale for selection of NOAELs or LOAELs when those are the only PODs that can be reliably used in Section 5.1. Specifically, regarding the Ozen study, this modeling has been revised and the UF_C_ lowered; the osRfC based on this study in the revised assessment is 0.006 mg/m^3^ and interpreted with low confidence.

The available evidence on susceptibility to the health effects of formaldehyde is synthesized in Section 4.1, with the primary application of that understanding to dose-response analysis for the studies advanced for toxicity value derivation (Section 5), including in the application of uncertainty factors (Section 5.1.3). As outlined in these sections, at least for pulmonary function and asthma, and likely for other respiratory effects, there is evidence to support that children, and asthmatic children in particular, are likely to be more sensitive. However, it is important to note that the assessment does not conclude that these effects do not occur in adults exposed to formaldehyde. Section 3.2.2 describes the consistent and strong evidence for declines in pulmonary function in workers with long-term exposure to formaldehyde (note: Appendix C.5 describes studies of pulmonary function in adults with short-term exposure); however, these long-term occupational studies generally only tested higher (≥ 0.2 mg/m^3^) levels of formaldehyde as compared to the residential studies, the latter of which sometimes included adults or adults and children. Section 3.2.3 highlights that there are few studies on the potential effects of formaldehyde on allergic conditions in adults, with concerns noted regarding the methods and imprecise results in those studies that prevent drawing a reliable judgment. However, Section 3.2.3 also shows that studies of workers with long-term exposure to formaldehyde collectively provide strong support for increases in asthma prevalence, but as above these findings are generally at higher formaldehyde levels (> 0.1 mg/m3) than the more sensitive residential- and school-based studies advanced for dose-response analysis for the purposes of developing an RfC. In addition to age, a host of additional factors (e.g., respiratory health; pre-existing disease; sex; smoking status; race) have been shown, sometimes with weaker evidence, to affect inter-individual variability in sensitivity for one or more of the health effects of formaldehyde. With few exceptions (i.e., large population studies encompassing a wide range of demographics, including reasonable representation of known or expected susceptible groups), the available studies are judged as unlikely to sufficiently address these differences in susceptibility, irrespective of the health outcome being considered. Consistent with EPA’s intent for an RfC and its definition, the RfC is applicable to all persons, including all lifestages as well as susceptible individuals, regardless of job status. Additional demographic details (e.g., information on age and sex) for the studies advanced for candidate value derivation have been added to the POD tables (Section 5.1.2) as further information supporting the UFs applied.

- Public Comment (Monell Chemical Senses Center): “While the POD for chemosensory detection and adaptive physiological response is not based on an adverse effect, formaldehyde odor detection, resulting in poor air quality, could be considered undesirable for consumers in their homes and workplaces, thus, justifying a guideline value, but not a regulatory limit.”
  “An increase in eye blinking or conjunctival redness is a normal adaptive response to external stimuli and not an adverse health effect. As such, a guideline value may be appropriate for lower concentrations of an irritant chemical (i.e., concentrations below 1 ppm), but developing a RfC based on the potential for adverse health effects on the eyes at lower concentrations is not supported by either individual studies or a weight-of-evidence approach.”
  “Despite the numerous controlled exposure studies that have demonstrated the effective concentrations for preventing eye irritation from formaldehyde, in the Draft US EPA/IRIS Assessment, studies [Hanrahan, Dally et al. 1984; Liu, Huang et al. 1991; Kulle, Sauder et al. 1987; Andersen and Molhave 1983] that are critically flawed and should have been excluded from the determination for dose-response were inappropriately advanced and used to derive or support a RFC of 0.009 mg/m^3^ for formaldehyde. In contrast, several controlled human exposure studies that are generally considered to be robust were not used to derive a RFC (Lang, Bruckner et al. 2008, Mueller, Bruckner et al. 2013). It is also well-acknowledged that the ability of a chemical to elicit odor occurs at (significantly) lower concentrations than its ability to elicit sensory irritation (Doty, Cometto-Muñiz et al. 2004). Despite this, the USEPA has proposed a RFC for sensory irritation that is well below the established threshold for odor. This inconsistency arises from the inappropriate use of and support by uninformative epidemiological studies with confounding variables that produce critical flaws. Following are concerns identified among the epidemiological or controlled exposure studies judged with medium confidence [Hanrahan, Dally et al. 1984; Liu, Huang et al. 1991; Kulle, Sauder et al. 1987; Andersen and Molhave 1983] that were used to derive or support a RfC based on sensory (eye) irritation.”
  “Overall, the reliance on historical symptom prevalence reports that are not obtained in conjunction with exposures raises serious concerns that an inappropriately low RFC is being derived. To date, no chemical has been identified as having an irritation threshold that is lower than its odor threshold and formaldehyde is no exception. Reliance solely on the data from the Hanrahan study has resulted in the identification of an irritation threshold that is orders of magnitude below the acknowledged odor threshold. The number of well-conducted controlled exposure trials with no evidence of ocular irritation between 0.3-0.5 ppm provide ample evidence that maintaining exposures at or below these concentrations will provide sufficient protection from sensory irritation, including eye irritation.”
  [Please see docket for details and supporting information.]
- Public Comment (Ramboll): “We were both co-authors of the Formaldehyde section of the World Health Organization Indoor Air Quality Guidelines for Select Pollutants (WHO 2010). We are concerned that the US Environmental Protection Agency (USEPA) evaluation of noncancer endpoints in the Draft document “Toxicological Review of Formaldehyde―Inhalation” largely ignores several important studies that the formaldehyde working group considered key. These recommendations were further endorsed by peer reviewers, and then the entire set of working groups and their reviewers. The recommendations were also published in a series of peer-reviewed journal papers by two of the WHO formaldehyde working group authors, Drs. Wolkoff and Nielsen…We were disappointed to see USEPA discount use of these high-quality studies [Mueller et al. 2013 and Lang et al. 2008], in favor of a population-based study where exposure was not controlled (Hanrahan et al 1984), which USEPA states was supported by older studies (Kulle et al 1993 or Andersen and Molhave 1983). The rationale provided was that the more recent chamber studies did not find a dose-response relationship. However, we note that one of these studies did not find any effect, even at the highest exposure, and the other study only found mild, chemosensory effects. This seems to discount better conducted studies simply because no effects were observed, which seems to be biased towards finding an effect where none exists. We believe that properly controlled human exposure studies are the “gold standard” for setting safe exposure limits, as they offer the major advantage of having defined exposure conditions, carefully characterizing volunteers, and altering experimental methods to consider potential confounding factors (Nielsen and Wolkoff, 2017). For example, people can detect the odor of formaldehyde at concentrations as low as 0.1 mg/m3 (WHO, 2010), which can interfere with subjective reporting of sensory irritation (Cometto-Muñiz and Cain 1991; Brüning et al., 2014). Controlled human exposure studies can add controls that mask these odors and their influence on subjective measures.
  We hope that USEPA will reconsider the studies serving as the basis of the reference concentration for sensory effects.”

EPA Response (to both public comments above): The revised assessment retains the identification of sensory irritation as a hazard and provides a toxicity value for this effect. This is consistent with the consensus 2023 NASEM peer review recommendations and prior advice in the 2011 NRC review, The decision criteria for the studies selected to support this toxicity value as well as the uncertainties in the selected studies and the other studies considered for deriving this value are described in the revised assessment (Section 5.1). Once a hazard has been identified, the goal of dose-response analysis is to calculate an RfC that is reasonably protective against those identified hazards, including in susceptible groups (see Sections 2.7 and 5.1, and the IRIS Handbook). Thus, in addition to evaluating the methodological conduct of the studies, the specific study populations and their diversity to represent the general population including a wide range of ages and health statuses, and the exposure scenarios (constant exposure vs peaks) are influential to the decision to advance or select certain studies. This is particularly true for an endpoint such as sensory irritation, which exhibits a large degree of inter-individual variability in sensitivity, and it is even more important when the considered studies are small. The chamber studies evaluating sensory irritation possessed these important limitations, which reduces their utility for the purposes of deriving a chronic RfC that is protective of a population.

The WHO guidelines (2010) cited by the commenter above state, “The short-term guideline will also prevent effects on lung function as well as long-term health effects, including nasopharyngeal cancer and myeloid leukaemia.” The WHO (2010) short-term guideline is based on sensory irritation in acute controlled exposure studies of healthy, middle-age human volunteers. Because the WHO analysis is quite brief (1-page), the scientific basis for this conclusion is not clear. WHO (2010) appears to reason that the short-term guideline is protective of long-term effects based on the following statements: (1) “There is no indication of accumulation of effects over time with prolonged exposure”; (2) “Neither increased sensitivity nor sensitization is considered plausible at such indoor concentrations in adults and children”; (3) “Indoor air effects of formaldehyde are expected to be limited to the site of contact, generally the nasal and upper airways”; (4) “Increased cell proliferation due to cell damage is considered a key mechanism for the development of nasal malignancies following exposure to formaldehyde… The NOAEL for cell proliferation [in rats] is 1.25 mg/m^3^ for long-term exposures” (Note: assuming a threshold for cancer, WHO applied to this NOAEL an interspecies factor of 3 and an interindividual variation factor of 2 to yield a value of 0.21 mg/m^3^); and (5) “An alternative approach was taken by several other groups, using a biologically motivated model… These two assessments (using a NOAEL/assessment factor approach and estimates from the biologically motivated models) yield similar results, with values of approximately 0.2 mg/m^3^.” The evidence basis supporting the above statements, the selected NOAEL, and the other decisions is not apparent in the WHO (2010) document. Because their estimate of 0.2 mg/m^3^ for cancer was higher than their short-term guideline, WHO (2010) concludes, “use of the short-term (30-minute) guideline of 0.1 mg/m^3^ will also prevent long-term health effects, including cancer.”

EPA does not consider this approach supported by the available evidence, particularly given the availability of well-conducted studies demonstrating several more sensitive health effects of formaldehyde after long-term inhalation exposure. In the available studies, these other health effects were either not evaluated after acute exposure or the effects were not observed at similar or even higher levels after acute exposure. Further, during the extensive review of the apical and mechanistic studies relevant to the portal of entry health effects of formaldehyde (hundreds of publications), EPA did not identify evidence to support the hypothesis that protecting individuals from developing sensory irritation would protect against other chronic noncancer health effects or cancer, particularly when considering human variability. Likewise, EPA did not identify evidence to support the hypothesis that sensory irritation is “upstream” of other health effects caused by formaldehyde inhalation (e.g., evidence supporting temporal- or exposure level-dependent biological linkages between key events for sensory irritation and those for the different health effects). EPA is not aware of any evidence to support the hypothesis that protecting against sensory irritation following acute exposure would be protective against chronic health effects. Biologically, such approaches would require assuming that formaldehyde levels that are too low to affect biological components (e.g., receptors) enough to cause detectable sensory irritation following an acute exposure are also too low to affect other biological components enough to cause any other effects, even with longer-term exposures. There seems to be no evidentiary basis to support this assumption.

Quantitatively, it is noted that the values (i.e., points of departure, PODs, and candidate RfCs, cRfCs, for chronic exposure) for sensory irritation are not among the most sensitive noncancer values in the IRIS assessment, and the values derived from the acute chamber studies of sensory irritation in intentionally exposed human volunteers are even less sensitive, with PODs generally an order of magnitude higher than many of the other chronic noncancer PODs. Thus, none of the sensory irritation values are protective against other sensitive noncancer health effects. In addition, based on the cancer IUR in the IRIS assessment, the selected IRIS cRfC for sensory irritation (i.e., based on the observational epidemiology studies by Hanrahan et al., 1984 and Liu et al., 1991) would be associated with a lifetime extra cancer risk of 2.2 × 10^−4^ (i.e. roughly 2 in 10,000 people at increased risk for developing cancer over their lifetime). Use of an IRIS cRfC for sensory irritation from the acute chamber studies (i.e., based on the preferred chamber study by Kulle et al., 1993) would be associated with an increased cancer risk in approximately four (4.4) in 10,000 people. For context, performing the same calculation using the IRIS RfC yields an extra cancer risk of 0.77 × 10^−4^ (increasing the lifetime cancer risk for roughly 8 in 100,000 people). While the IRIS cRfC based on cytotoxicity-induced regenerative hyperplasia is higher (less sensitive) than the selected IRIS cRfC for sensory irritation based on the human observational studies (Hanrahan et al., 1984 and Liu et al., 1991), it is several-fold lower (more sensitive) than the cRfC derived from the preferred chamber study (Kulle et al., 1993). That is, a toxicity value based on sensory irritation from the chamber studies would not only be inadequate to protect against cancer, but it would also be inadequate to protect against cytotoxicity-induced cellular proliferation contributing to cancer development (noting that this represents only one of at least two independent pathways contributing to cancer development). In summary, none of the values (PODs or cRfCs) based on sensory irritation are protective against other noncancer health effects or cancer.

- Public Comment (American Chemistry Council): “In addition to these studies [Lang et al. 2008 and Mueller et al. 2013] of irritation following short-term exposures, multiple studies have also been conducted in animals focused on objective measurements of tissue irritation, cell proliferation and cytotoxicity following short-term repeated dose exposures (Swenberg et al. 1983a, 1983b; Monticello et al. 1991; Monteiro-Riviere and Popp 1986). Although some of these studies were discussed by EPA under the category “respiratory pathology” with robust evidence, they are objective evidence of an adverse effect, tissue irritation, following short-term exposures and would thus be more relevant for deriving an irritant RfC.”
  “EPA should use objective measures of adverse effects for developing noncancer RfCs.” [Please see docket for details and supporting information.]

EPA Response: EPA does not agree that the animal studies mentioned by the commenter are appropriate to represent the identified hazard of sensory irritation (separately, please see comment responses relating to Lang and Mueller in Appendix F.3.2 on sensory irritation). The available evidence also does not support that the tissue changes in these short-term studies are appropriate for derivation of a chronic RfC, as these effects clearly worsen with continued exposure. However, the assessment does consider these studies and as mentioned by the commenter, presents a toxicity value for respiratory tract pathology. The assessment also leverages related effects for derivation of an RfC-based value for one MOA contributing to the development of cancer, cytotoxicity-induced regenerative proliferation.

- Public Comment (ToxStrategies): “On page 1-154 of the Toxicological Review, EPA states that most of the studies reporting histopathological changes in humans had average exposures ranging from 0.05 to 0.6 mg/m3. EPA speculates that these workers are likely less sensitive to formaldehyde than the average person, characterizing them as “survivors” of long-term irritant exposure. This appears to be complete speculation and, to this reviewer, undermines the credibility of the assessment. Notably, there were no high confidence studies in humans. Among the four medium confidence studies, one (Boysen et al. 1990) was characterized by EPA as equivocal. Importantly, all the studies found relatively mild differences in nasal histopathology when plant workers were compared to non-plant workers (see table below). Many of the plant workers were exposed to wood dust and likely other chemicals. As shown in the table below, many of the individuals in the referent groups appear to work in very different professions with different environmental settings (e.g., factory vs hospital). These comparison groups do not appear to be suitable for ascribing any observed differences to formaldehyde with any certainty.”

EPA Response: The potential for a “healthy worker” effect is an established concern (with a clear bias towards the null) for analyses of occupational populations in epidemiology studies. However, the specific wording about “survivors” has been removed in the revised assessment to focus on the specific concern for potential “survival bias” as follows: “These were cross-sectional studies of current workers who may have been less sensitive to the long-term respiratory irritant effects of formaldehyde, which would cause survival bias and an attenuation of comparisons between exposed and comparison groups.”

- Public Comment (American Chemistry Council): “EPA did not derive, and present for comparison, an RfC for upper respiratory tract effects, based on cytotoxicity, as directed by the NAS (2011).”
  “The Draft Assessment often confuses the difference between an adverse and compensatory response, leading to the development of RfCs based on compensatory rather than adverse responses, which is prohibited by EPA guidelines for risk assessment. Hyperplasia and metaplasia are often compensatory responses, as recognized in the Draft Assessment, but then considered adverse and used for developing RfCs.” [Please see docket for details and supporting information.]

EPA Response: The commenter is incorrect. The assessment estimates and discusses RfC-based values for one MOA contributing to the development of cancer, cytotoxicity-induced regenerative proliferation (see Section 5.2.1 in the revised assessment). It is noted that both hyperplasia and metaplasia can pre-dispose a tissue to neoplastic changes and squamous metaplasia is interpreted as an adverse change on its own (i.e., separate from its potential association with cancer) (Section 3.2.4). Peer reviewers supported these conclusions.

- Public Comment (American Chemistry Council): “The Draft Assessment chose to exclude available data but adds uncertainty factors to the POD to account for lack of these same data. The Draft Assessment (p. 2-28) when justifying an uncertainty factor being applied for extrapolation of subchronic to chronic exposure for respiratory tract pathology states: ‘A factor of 3 was applied to the respiratory tract pathology POD from Kerns et al. (1983) because it was based on 18-month exposure data from that rodent study in lieu of the 24-month exposure data available in the same study.’ First, it is noteworthy that the 24-month NOAEL for respiratory tract pathology is the same as that defined for the 18-month exposures. Second, the Draft Assessment, in the same paragraph, provides a contradictory analysis by first stating: ‘…there are data to suggest that exposure concentration would be more important to the development of this lesion than duration’ and ‘a lower POD would have been expected if the 24- month data could have been modeled.’ Speculation on what would be “expected,” does not present a strong case for adding uncertainty factors for the absence of the excluded data. Thirdly, there are internal inconsistencies in the Draft Assessment when determining to ignore the 24-month data of Kerns et al. (1983)… There is no rationale for concluding that a preference for a shorter-term value from the same study is inappropriate in one study evaluation, but acceptable for another study evaluation.”
  “The Draft Assessment lacks transparency in the quantitative assessments and conservatism in proposed exposure limits is introduced by the use of modeling practices and exposure concentration adjustments that are ill defined. In addition, insufficient rationale is provided and most often relegated to footnotes. Some resulting uncertainty adjustments exceed the limits defined by EPA.”

EPA Response: As discussed previously, the 24-month data could not be modeled. The statements about the data at 24-months resulting in a lower POD are not speculative but rather based on the incidence information available at 24 months versus 18 months. There is a clear increase in the severity of the response at 24 months as compared to 18 months in this dataset and thus the UF = 3 is retained in the revised assessment. It is noted, however, that due to lower confidence in the candidate value based on this study, it was not selected as the osRfC for respiratory tract pathology.

- Public Comment (Toxicology Excellence for Risk Assessment): “…EPA should focus on the area of critical effect and not belabor effects that are clearly well advanced in formaldehyde’s underlying mode of action. For example, estimating a Reference Concentration (RfC) for a pathological endpoint that only occurs well above a No Observed Adverse Effect Level (NOAEL) for tissue irritation is non-sensical. Furthermore, EPA has some exquisite human data in hand including data in sensitive subgroups. EPA needs to recognize that a NOAEL for such data are, in effect, the RfC, as per its own definition of RfC. In such cases, no additional uncertainty factors are needed for within-human variability, as readily demonstrated by prior EPA judgments found on its Integrated Risk Information System (IRIS).”
- Public Comment (American Chemistry Council): “The Draft Assessment presents RfCs for a number of non-cancer systemic effects, including reproduction/developmental effects in females and reproductive toxicity in males. NAS (2011) identified this as problematic and not supported by the evidence.”
  “The Draft Assessment does not integrate available data, as required when reaching conclusions; individual RfC and Inhalation Unit Risk (IUR) factors were calculated based on individual study results with only uncertainty factors added and/or linear extrapolations. The exception is an inappropriately averaged RfC for female reproductive or developmental toxicity.” [Please see docket for details and supporting information.]

EPA Response (to both public comments above): All decisions and supporting justifications for the noncancer dose-response assessment are described in Section 5.1 of the revised Toxicological Review. This includes decisions for study selection, POD derivation, uncertainty factor application, candidate value calculations and confidence, and selection of the RfC. The NASEM peer review panel had no Tier 1 recommendations on the RfC, and EPA has addressed all other panel comments on this topic.

## F.4 NASEM REPORT CHAPTER 5: CANCER; CHARGE QUESTION 6: CANCER AND CHARGE QUESTION 7: IUR FOR CANCER

### F.4.1 Hazard Identification

#### Charge Question 6. Cancer

The assessment concludes that formaldehyde is Carcinogenic to Humans by the Inhalation Route of Exposure. Please comment on whether the judgments in (a) to (f), below, are clearly described and scientifically justified. Note that the three judgments in (a), (b), and (c) outline the primary evidentiary support, and that each of these judgments would independently substantiate the carcinogenicity conclusion.

a. The evidence demonstrates that formaldehyde inhalation causes nasopharyngeal cancer (NPC) in humans, based primarily on observations of increased risk of NPC in groups exposed to occupational formaldehyde levels and evidence of nasal cancers in animals, with strong, reliable, and consistent mechanistic evidence in both animals and humans, including support for a mutagenic MOA.
b. The evidence demonstrates that formaldehyde inhalation causes sinonasal cancer (SNC) in humans, based primarily on observations of increased risk of SNC in groups exposed to occupational formaldehyde levels and supported by the evidence of nasal cancers in animals, with consistent mechanistic evidence and support for a mutagenic MOA.
c. The evidence demonstrates that formaldehyde inhalation causes an increased risk of myeloid leukemia in humans, based primarily on observations of increased risk in groups exposed to occupational formaldehyde levels. This judgment is supported by other studies of human occupational exposure that provide strong and coherent mechanistic evidence identifying clear associations with additional endpoints relevant to lymphohematopoietic (LHP) cancers, including an increased prevalence of multiple markers of mutagenicity and genotoxicity in peripheral blood cells of exposed workers, other perturbations to immune cell populations in blood (primarily from human studies). Generally, evidence supporting the development of LHP cancers after formaldehyde inhalation has not been observed in experimental animals (i.e., rodents), including a well-conducted, chronic cancer bioassay in two species, a similar lack of increased leukemias in a second rat bioassay, and multiple mechanistic evaluations of relevant biological changes such as genotoxicity in systemic tissues of exposed rodents. The lack of findings in animals does not detract from the strong human evidence.
d. The overall conclusion on the carcinogenicity of inhaled formaldehyde was independently supported by the three sets of evidence outlined in 6a-6c above. This carcinogenicity conclusion was not influenced by the judgments for several other cancer types. Specifically, the evidence suggests, but is not sufficient to infer, that formaldehyde inhalation might cause oropharyngeal/hypopharyngeal cancer, Hodgkin lymphoma, or multiple myeloma in humans; there is inadequate evidence to determine whether formaldehyde inhalation may be capable of causing laryngeal cancer or lymphatic leukemia in humans.
e. Formaldehyde is genotoxic in several test systems and operates, at least in part, through a mutagenic MOA. Specifically, a mutagenic MOA was identified in association with the development of nasal (i.e., nasopharyngeal and sinonasal) cancers, while no MOA was identified for other cancer types. The mechanistic evidence was sufficient to conclude that both mutations and cellular proliferation play a role in nasal carcinogenesis.
f. The MOA(s) leading to cancer formation outside of the respiratory tract are unknown.

#### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 3 Tier 2 Suggested Revisions
- 0 Tier 3 Future Considerations
- 13 Consensus Panel Findings (numbered below)

#### Organization, Literature Identification and Evaluation of Study Methods

##### Peer Review Findings and Comments

- Finding (1): The overall organization of the information on cancer effects of formaldehyde is appropriate and commensurate with prior recommendations from the NRC. The focus on respiratory tract cancers and cancer of the lymphohematopoietic system, but not other cancer types, is appropriate and justified.
- Finding (2): With respect to cancer hazard evaluation, EPA adequately and transparently evaluated the scientific literature using methods consistent with its state-of-practice methods. Sections of the 2022 Draft Assessment describing the methods used for identifying and evaluating studies of formaldehyde and cancer in humans and animals, as well as mechanistic evidence, are voluminous and extensive but well organized. EPA did not have the final version of the IRIS Handbook while it was developing the 2022 Draft Assessment, and also had the additional challenge of a 4-year hiatus during which no work could be performed on this assessment. Nonetheless, the overall process used and choices made are consistent with EPA’s state-of-practice methods and responsive to the recommendations of the 2011 NRC committee.

##### Related Public Comments

- Public Comment (Thomas B. Starr): “These comments are directed at EPA’s discussions of the collaborative research conducted by myself and Dr. James A. Swenberg on a novel “bottom-up” approach to bounding human cancer risks that could arise from chronic inhalation exposure to low levels of airborne formaldehyde. This work has been described in three peer-reviewed publications (Swenberg et al. 2011, and Starr and Swenberg 2013 and 2016). It has also been addressed critically in a “Letter to the Editor” by Crump et al. (2014), and our response to that letter (Starr and Swenberg 2014), the latter of which is not discussed or even cited in the Draft IRIS Toxicological Review, its reference list, or the Supplemental Information for Formaldehyde document. More recently, Hartwig et al. (2020) and Lu et al. (2022) have reviewed (positively) the “bottom-up” approach in two additional peer-reviewed articles, neither of which is discussed or cited in these EPA documents. EPA’s failure to cite our response to Crump et al.’s 2014 letter and the two more recent peer-reviewed articles calls into question the completeness (and validity) of EPA’s Systematic Review process.”

EPA Response: The Starr and Swenberg (2014) response to Crump (2014) is cited in the revised assessment in Section 5.2.1. EPA Note: reviews and studies with no primary data are considered as supplemental materials and tracked in HERO.

- Public Comment (Natural Resources Defense Council): “Comments from NIOSH identified three genotox studies – Chebotarev et al 1986, Vasudeva and Anand 1996, Yager et al 1986 - that are not included in EPA’s evaluation, that provide experimental evidence supporting a genotoxic mechanism of toxicity for formaldehyde. While the first is in Russian, an English abstract is available, and for the other two they are available in English. If EPA is excluding all studies that are not in English, this is problematic and deserves some discussion and scrutiny.” “NIOSH commenters also noted the failure to include an important published meta-analysis of myeloid leukemia risks in occupationally exposed workers, focused on occupations known to have high formaldehyde exposures by Zhang et al 2009. The study shows a statistically significant 1.5X increase leukemia in 15 studies (RR=1.54, CI 1.18-2.00), and an almost 2-fold higher risk for myeloid leukemia in six studies (RR=1.90, CI 1.31-2.76). Omission of this important paper should be corrected.”

EPA Response: Two of the three noted studies are cited in the Appendix C.3; the third is tagged in HERO as supplemental. To clarify, non-English studies are not excluded although they are not necessarily translated [see also IRIS Handbook (U.S. EPA, 2022)]. EPA staff consider the criticality of non-English studies (e.g., based on a translated abstract or review by a native speaker) with respect to their potential impact on assessment conclusions. Non-English papers considered unlikely to have a substantial impact, such as this one on a topic for which there are many studies, were not translated.

- Public Comment (Cardno ChemRisk [now Stantec]): “The EPA also disregarded the Mundt et al. (2018) summary of relevant studies [Meyers et al. 2013; Coggon et al. 2014; Talibov et al. 2014; Saberi Hosnijeh et al. 2014] published in the 6 years following the NRC review of EPA’s Draft IRIS Toxicological Review of Formaldehyde and addressing several gaps identified by the NRC…EPA’s characterization of the literature published since the 2010 IRIS draft is limited and would have been informed by the summaries provided in Mundt et al. (2018).”
  “I reviewed the recently released IRIS Toxicological Review of Formaldehyde (Inhalation) (External Review Draft, 2022) to assess the accuracy and completeness of my formaldehyde research publications. Specifically, I identified all occurrences of citations to my publications in each of the IRIS documents (Main Text, Overview document, and Supplementary Materials), then evaluated the presentation of the information (i.e., risk estimates) and the interpretation of these publications.
  As detailed further below, I have published 18 formaldehyde publications, but the Draft only cites 10. Several of the omitted papers were critical contributions to the literature on the potential human health effects of formaldehyde. Additionally, in several instances, EPA has mis-interpreted and mis-cited my publications in a manner that substantively affects the interpretation of these individual studies and the overall weight of the evidence regarding formaldehyde carcinogenicity.
  EPA should consider re-reviewing all 18 publications and updating the Draft to add missing studies, correct citation errors, and revise the language characterizing the findings of these studies.” [Please see docket for details and supporting information.]

EPA Response: The primary data studies indicated by the commenter are cited in the assessment. The eight “missing” citations are reviews and were tagged as supplemental material. As described in prior responses and the assessment methods (Section 2.2), reviews and studies with no primary data are considered as supplemental materials and tracked in HERO. However, supplemental studies are not necessarily cited in the assessment, in particular if they are reviews of studies that meet the assessment PECO criteria. EPA conducts an independent analysis of the studies meeting PECO criteria.so the stance of EPA on the impact and utility of the papers to inform assessment conclusions can differ from the views and conclusions expressed by the study authors.

#### Study Evaluation

##### Peer Review Findings and Comments

- Finding (3): EPA followed a transparent and reasonable approach in evaluating the studies relevant to cancer in humans and in animals, and in providing mechanistic evidence to support its analysis. EPA followed the state of practice for literature review at the time the assessment was being conducted in evaluating studies of cancer outcomes in humans and in animals. For mechanistic evidence, EPA used a narrative review approach for summarizing the voluminous evidence on mechanistic events that are known to be associated with cancers of the upper respiratory tract and lymphohematopoietic cancers. Studies supporting and refuting the proposed mechanistic hypotheses were evaluated in a balanced and transparent manner.

EPA Response to Finding 3: For transparency, EPA notes that one study was downgraded from high to medium confidence for LHP cancers in the revised assessment based on analyses of consistency in study evaluations (Kerns et al., 1983).

##### Related Public Comments

- Public Comment (University of North Carolina at Chapel Hill): “The IRIS Draft significantly underestimated the impact of co-exposure on the confidence in assessing how formaldehyde may lead to leukemia and associated mechanistic events in both experimental animal models and humans…The results [Lu, Gu, et al. 2012] strongly indicate that studies confounded by methanol in exposure should be excluded from any rigorous risk assessment of formaldehyde. The EPA IRIS Draft acknowledges that methanol may influence the confidence of assessment by stating ‘although results may be confounded by methanol co-exposure (low confidence).’ However, the EPA IRIS Draft still used these studies to support several hypothesized mechanistic events associated with formaldehyde induction of lymphohematopoietic cancers.” “Recommendation: The EPA IRIS Draft needs to discuss how methanol co-exposure significantly impacts evidence-based risk assessment of formaldehyde. Any study, including epidemiology studies, with potential methanol co-exposure should be excluded from the integration of evidence, as methanol seriously confounds the finding and potential understanding of mechanistic events.” [Please see docket for details and supporting information.]

EPA Response: EPA has thoroughly and transparently evaluated the published studies on LHP cancers using methods, and arriving at judgments, supported by the consensus peer review panel (Finding 3 above). Please see Appendix B.3.9 in the revised assessment for a discussion of methanol co-exposure.

- Public Comment (University of California San Diego): “The EPA mischaracterized the findings of the reanalysis of the NCI cohort study by Checkoway et al. (2015) and downgraded the exposure assessment without consideration of the issues with the peak exposure definition in the Beane Freeman et al. (2009) analysis of myeloid leukemia (addressed in Checkoway et al. 2019)…”
  “EPA misinterpreted the impact of defining an absolute peak exposure metric on the study findings….”
  “The EPA assigned low confidence to the exposure assessment in Checkoway et al. (2015) due to purported information bias and low sensitivity and suggested that the direction of expected bias would be toward the null, representing an underestimation of the actual risk. In fact, there is no such evidence of a bias toward the null in the reanalysis…”
  “We also published a comprehensive review of approaches to characterizing peak exposures and deriving cancer potency values from the epidemiological literature. Our analysis included nine epidemiological studies of environmental chemicals classified as carcinogens, including formaldehyde (Checkoway et al., 2019). This analysis provides additional valuable information that EPA should have considered and incorporated when evaluating the Checkoway et al. (2015) analyses conclusions to inform its approach to quantitative cancer potency characterization in the 2022 draft IRIS. Specifically, in addition to succinctly summarizing the results of the Checkoway et al. (2015) analysis, it also identifies issues with the characterization of peak exposure in in a case-control study of embalmers (Hauptmann et al. 2009). Furthermore, Checkoway et al. (2019) identified a pattern of limitations associated with using peak exposure data from epidemiological studies of seven additional substances (benzene, trichloroethylene, acrylonitrile, ethylene oxide, methylene chloride, styrene and/or butadiene) to inform risk characterization. Thus, the lack of a uniform approach is a critical issue that is not limited to formaldehyde. These methodological challenges include variability in peak exposure definitions across studies, lack of direct peak exposure measurements and reliance on expert judgement for exposure classifications, and potential exposure misclassification. The 2022 draft IRIS should have referred to this paper to better understand the limitations of the underlying formaldehyde epidemiological literature particularly with respect to the characterization of “peak” exposures to formaldehyde in some studies. Perhaps most importantly, the Checkoway et al. (2019) analysis substantiates the findings of Checkoway et al. (2015). The clear lack of an association with myeloid leukemia and its subtypes (AML and CML) in relation to cumulative exposure (the default exposure metric in epidemiologic studies based on its incorporation of both intensity and duration of exposure) do not support a causal association at any exposure level (Checkoway et al., 2015).”
  [Please see docket for details and supporting information.]

EPA Response: EPA considered the methods of defining peaks in Checkoway et al. (2015) in Section 3.3.3 and noted that “In Beane Freeman et al. (2009), for peak exposure there were four cases of ML who were unexposed, 14 cases with peak exposure from >0 to <2 ppm, 11 cases with peak exposure from 2 to <4 ppm, and 19 cases with peak exposure ≥4 ppm. In Checkoway et al. (2015), the new definition of peak exposure and the recategorization resulted in 27 cases of ML with peak exposures from 0 to <2 ppm, 11 cases with peak exposure from 2 to <4 ppm, and 10 cases with peak exposure ≥4 ppm. The Checkoway et al. (2015) results were classified with low confidence due to information bias and low sensitivity.” A footnote in Table 4 of Checkoway et al. (2015) says that Referent group includes study subjects with peaks less than 2 ppm of hourly, daily, weekly, and monthly frequency as well as peaks 2 ppm or more if hourly or monthly frequency. Reclassification of subjects who were judged to have experienced formaldehyde exposures in excess of 2 ppm in the Beane Freeman et al. (2009) to the reference category (>0 and < 2 ppm) in Checkoway et al. (2015) because those exposures of greater that 2 ppm occurred hourly or monthly had the mathematical effect of attenuating the observed effect reported in Beane Freeman et al. (2009). No explanation was provided of why exposures greater that 2 ppm that occurred hourly or monthly should have been discounted and EPA judged there to be potential bias towards the null and an overall rating of low confidence.

#### Evidence Syntheses and Synthesis Judgments for Cancers of the Upper Respiratory Tract

##### Peer Review Findings and Comments

- Finding (4): With respect to cancer hazard identification for respiratory tract cancers in humans exposed to formaldehyde, EPA synthesized the current state of the science in a manner consistent with its state-or-practice methods and presents conclusions based on its expert judgment with the support of the available scientific evidence.
  ○ Related committee text: While there is uncertainty in the degree to which nonmutagenic processes may also contribute to the carcinogenic activity of formaldehyde inhalation at the point-of-entry tissues, there is sufficient evidence to support the assumption that a mutagenic MOA is involved in the carcinogenesis of formaldehyde in the upper aerodigestive tract in humans.
- Tier 2 Suggested Revision (Recommendation 5.1): While the narrative describing the application of criteria for each site is well done, EPA should enhance clarity by providing explicit statements in Section 1.2.5 summarizing synthesis judgments for each criterion (consistency, strength, temporal relationship, exposure-response relationship, etc.).

EPA Response to Tier 2 Suggested Revision 5.1: Brief synthesis judgments have been added following each criterion judgment in the respiratory cancer section (now Section 3.2.5) and in the lymphohematopoietic cancer section (now Section 3.3.3).

- Tier 2 Suggested Revision (Recommendation 5.2): For consistency, EPA should add a summary of the data and evidence synthesis for laryngeal cancer after page 103 of the Assessment Overview.

EPA Response to Tier 2 Suggested Revision 5.2: The Overview has not been retained in the revised assessment.

- Finding (5): With respect to cancer hazard identification for respiratory tract cancers in animals exposed to formaldehyde, EPA synthesized the current state of the science in a manner consistent with its state-of-practice methods and presents conclusions based on its expert judgment with the support of the available scientific evidence.
- Finding (6): With respect to evidence on MOA for upper respiratory tract cancers, EPA used its state-of-practice methods to synthesize the evidence.
- Finding (7): EPA presents an overall clear and succinct evidence integration summary for effects of formaldehyde inhalation on upper respiratory tract cancers. EPA followed its state of practice for evidence integration at the time the 2022 Draft Assessment was being developed in evaluating studies of cancer outcomes in humans and animals, as well as mechanistic evidence.
- Finding (8): EPA integrated the mechanistic evidence in considering biological plausibility for the human or animal evidence. However, it separately presents MOA considerations in the “other inferences” section of the evidence integration table (for this endpoint and for other endpoints throughout the 2022 Draft Assessment). The IRIS Handbook calls out “other critical inferences” as a factor to address in evidence integration (EPA, 2022, pp. 6-1 and 6-2 in the Assessment Overview; Chapter 6 of the Main Assessment). This concept is applied in the evidence integration sections throughout the Draft Assessment, but the term “other inferences” is not explained. See Chapter 2 of the present report, Recommendation 2.5.

EPA Response to Finding 8: As noted previously, the “other inferences” are now better defined in the assessment methods and the specific inferences relevant to each health effect-specific decision more clearly documented within each evidence integration section (and supporting table). This has also been clarified in the methods (primarily Section 2.5 of the revised Toxicological Review).

##### Related Public Comments

- [underlined: Public Comment (American Chemistry Council)][underlined: :] “EPA should evaluate carcinogenicity entirely under its 2005 Guidelines for Cancer Risk Assessment (2005 Guidelines). The 2005 Guidelines and descriptors have not been harmonized with the re-purposed GRADE framework and descriptors used in the IRIS Handbook.”
  “The 2022 Draft Assessment must comply with EPA’s guidelines for carcinogenic risk assessment…In implementing its Information Guidelines, EPA relies on existing guidelines and policies, which includes EPA’s Guidelines for Carcinogenic Risk Assessment (Cancer Guidelines). The Cancer guidelines explicitly note that ‘when judging and considering the use of any data, the basic standard of quality, as defined by the EPA Information Quality Guidelines, should be satisfied.”
  “Thus, the 2022 Draft Assessment fails to rely on the best available science and apply a transparent and systematic review incorporating a weight-of-evidence approach that properly integrates evidence streams in assessing potential non-cancer and cancer risks of formaldehyde exposures, especially at human relevant, low levels of exposure. Moreover, EPA repeatedly cites its Cancer Guidelines but fails to properly apply them. As a result, EPA’s linear unit risk estimate for NPC is essentially unchanged from the value derived over 30 years ago, despite the prodigious growth in the scientific database on formaldehyde indicating that formaldehyde is a threshold carcinogen.”
  “The Draft Assessment often states the assessment followed EPA’s Cancer Guidelines (U.S. EPA 2005), without citation. Likewise, there is no discussion of rationale for departing from the Guidelines when it did.”
  “Regarding evidence synthesis and integration within and across lines of evidence, the 2022 draft Formaldehyde Review does not follow best practices for systematic review. Perhaps most importantly, there is a greater reliance on “strength” rather than “weight” of evidence. For example, the draft concludes that that the strength of the human evidence for myeloid leukemia is “robust” based on “several” studies with consistent findings. EPA’s conclusion is based largely on the Beane Freeman analyses of the NCI cohort (pg. 1-542). EPA did not appropriately integrate apparently conflicting findings in the older epidemiological studies (Hauptman et al. (2009) funeral workers study, Beane Freeman et al. (2009) analysis of the NCI cohort) with the analyses published more recently, which demonstrate no excess in cancer risk (e.g., Checkoway et al. (2015) re-analysis of the NCI cohort). EPA should re-examine its evaluations of study confidence (and risk of bias, especially including statistical analyses) and more fully integrate and interpret the earlier studies in the context of the broader body of more informative and updated studies.”
  “Strength and weight of the evidence determinations in animal studies are often subjective, unfounded, and contradictory.”
  “EPA’s treatment of mechanistic data continues to be problematic. As EPA notes on page xxxviii, “the lack of mechanistic data explaining an association did not discount results from human or animal health effect studies.” While very strong, consistent and positive evidence in animals and humans, indicative of an effect, is often sufficient to make some conclusions on the likelihood of human health risk, in most cases, there is some inconsistency both within and across the animal and human streams of literature, which makes mechanistic information exceedingly important. EPA should give more weight to mechanistic information, particularly when it exists and does not support a human-relevant mechanism. The Agency for Toxic Substances and Disease Registry (ATSDR) echoed this concern in their interagency review comments.”
  “The 2022 Draft Assessment fails to incorporate a weight of evidence approach or properly integrate evidence streams in assessing non-cancer and cancer endpoints.”
  “The 2022 Draft Assessment does not incorporate best practices for evidence synthesis…The process of evidence synthesis (within lines of evidence) and evidence integration (across lines of evidence) are critical but still somewhat underdeveloped areas of systematic review. In the 2022 Draft Assessment, the procedure is described, but only in general terms, as depicted in the figure below (a figure that is found in the 2022 Draft Assessment but does not appear in the IRIS Handbook). Further, it is notable that there is no discussion of mechanistic studies or information on MOA.”
  “The 2022 Draft Assessment does not incorporate best practices for evidence integration. In 2011, NASEM gave the following recommendation (in this case, in regard to the lymphohematopoietic malignancies): As stated in EPA’s cancer guidelines, EPA’s approach to weight of evidence should include ‘a single integrative step after assessing all of the individual lines of evidence.’ Although a synthesis and summary are provided, the process that EPA used to weigh different lines of evidence and how that evidence was integrated into a final conclusion are not apparent in the draft assessment and should be made clear in the final version.”
  “NASEM (2011) went on to criticize the 2010 Draft Assessment for the lack of a clearly articulated framework for establishing causation on the ‘basis of the weight and strength of the evidence.’ EPA reports that it implemented NASEM’s recommendations by evaluating studies related to each endpoint using “a common evidence integration framework for determinations of causality” with rationales described in the integrated summaries of evidence (Appendix D of the 2022 Draft Assessment). Indeed, EPA has developed a framework for weighing evidence, informed by Bradford Hill postulates (as recommended by NASEM 2011) as presented in the IRIS Handbook and the 2022 Draft Assessment. However, as applied, the integration process requires substantial scientific judgment, and the 2022 Draft Assessment does not clearly describe the way in which evidence was synthesized and integrated to reach its determinations of causality.” [Please see docket for details and supporting information.]
- Public Comment (Louisiana Chemical Association): “The classification of ‘evidence demonstrates’ that formaldehyde causes nasopharyngeal cancer (NPC) and sinonasal cancers is not fully supported and should be reevaluated based on the growing amount of information which argues against a causal association. Based on EPA guidelines (Table 8 of EPA 2022a), the classifications of ‘evidence indicates’ is more appropriate given the conflicting and inconsistent findings in human epidemiological studies, the indications of chance, bias and confounders in key positive epidemiological studies, and the stronger but limited evidence in high exposure rat studies.”

EPA Response (to both public comments above): The assessment continues to adhere to EPA’s 2005 cancer guidelines (U.S. EPA, 2005) in evaluating and judging the available scientific evidence on cancer. The assessment decisions on cancer were supported by the consensus peer review panel (see findings above). The NASEM panel provided no Tier 1 recommendations on this topic and EPA has addressed the other panel comments on this topic.

Specifically, regarding NPC, the judgment of evidence demonstrates is based on robust human evidence of increased risk in groups exposed to occupational formaldehyde levels, and robust animal evidence of nasal cancers in rats and mice that exhibits steeply increasing incidence at high formaldehyde levels. Strong mechanistic support is provided across species (primarily rats, but also mice, monkeys, and humans), including genotoxicity, epithelial damage or remodeling, and cellular proliferation that are consistent with neoplastic development in a regional, temporal, and dose-related fashion. Mutagenicity- and cell proliferation-based MOAs both contribute. This is described in Section 2.3.5.

The judgment of evidence demonstrates for myeloid leukemia is based primarily on observations of increased risk in groups exposed to occupational formaldehyde levels. This judgment is supported by other studies of human occupational exposure that provide strong and coherent mechanistic evidence identifying clear associations with additional endpoints relevant to lymphohematopoietic (LHP) cancers, including an increased prevalence of multiple markers of mutagenicity and genotoxicity in peripheral blood cells of exposed workers, other perturbations to immune cell populations in blood (primarily from human studies). The few animal studies on LHP cancers do not contribute to this judgment. The MOA is unknown. This is discussed in Section 3.3.3.

EPA Note: Interagency reviewer (e.g., ATSDR) comments were on a draft prior to revision for public release. Please consult the full interagency review comments in the EPA docket.

Although not influential to the independent evaluations of all identified, pertinent, primary information performed in the IRIS assessment, the conclusions on cancer by other federal and international agencies are summarized in Appendix G. Specifically, the hazard conclusion for human carcinogenicity in the IRIS assessment is consistent with those drawn by other expert review panels. Formaldehyde was classified as a known carcinogen by the (NTP, 2011a) and a Group 1 carcinogen by (IARC, 2006, 2012), both based on evidence for nasal cancers in humans and animals and myeloid leukemia in humans, with supporting data on mechanisms of carcinogenesis. In addition, an expert committee convened by the NAS confirmed the conclusions of the NTP 12^th^ Report on Carcinogens (RoC) and conducted an independent review of the literature through 2013, concluding that formaldehyde is a known carcinogen. The European Union and Health Canada concluded that formaldehyde is a genotoxic carcinogen with a cytotoxic MOA (SCOEL, 2017; Health Canada, 2001, 2006; ECHA, 2012). Contrasting this, the conclusions reached in the IRIS assessment are consistent with those concluded by (IARC, 2012);(NTP, 2014), and the (NRC, 2014). Notably, in these latter assessments, there was widespread, general agreement that the available genotoxicity evidence is largely consistent and strong, particularly in circulating blood cells. From IARC 2012: “Mechanistic evidence supporting a causal relation between inhalation of formaldehyde and induction of cancer of the nasopharynx and nasal sinuses is based on the chemical reactivity of formaldehyde in producing DNA–protein crosslinks, and its genotoxicity in vitro and in vivo, including in the nasal cells of exposed humans… Local effects in the nasal passages, genotoxicity, and cell-proliferation rate appear to be the major determinants of nasal carcinogenicity after exposure to formaldehyde… The current data strongly indicate that genotoxicity plays an important role in the carcinogenicity of formaldehyde in nasal tissues in humans, and that cellular replication in response to formaldehyde-induced cytotoxicity promotes the carcinogenic response.” From NTP RoC 15th: “Formaldehyde causes genetic damage to the nasal tissues of both experimental animals and humans exposed by inhalation… Inhalation-exposure studies in experimental animals have shown that airway deposition and cytotoxicity-induced cellular proliferation also are important factors in the carcinogenicity of formaldehyde to nasal cells… Formaldehyde exposure also causes cytotoxicity and cellular proliferation at anatomical sites that are not thought to be the origin of the squamous-cell carcinoma, suggesting that factors other than cellular proliferation play a role in formaldehyde-induced nasal cancers.” From NTP RoC background document (2010): “Formaldehyde is a direct-acting genotoxic compound that affects multiple gene expression pathways, including those involved in DNA synthesis and repair and regulation of cell proliferation.”

- Public Comment (Formacare): “Formaldehyde is a very well-known chemical. It is one of the first registered under the EU REACH regulation (EC) No 1907/2006 and benefits from decades of extensive scientific research.
  Formaldehyde is already highly regulated: consumer and worker safety are ensured in the European Union via harmonised classifications under the (EC) No 1272/2008 Regulation, existing and forthcoming REACH restrictions and the implementation of an EU-wide Binding Occupational Exposure Limit (BOEL). This BOEL is based on the evaluation of the European Scientific Committee on Occupational Exposure Levels (SCOEL) which derived an occupational exposure limit (OEL) of 0.3 ppm TWA and a short-term exposure limit (STEL) of 0.6 ppm. The opinion of the SCOEL was joint to this submission.
  An important prerequisite for the derivation of these exposure limits was the categorization as a so-called group C carcinogen, i.e. a genotoxic carcinogen with a mode-of-action based threshold. For all relevant steps of local carcinogenesis, clear No-Observed-Adverse-Effect-Concentrations (NOAECs) could be identified (cf. page 9 of the [submitted] joint SCOEL document):
  ‘Experimental studies support that the local carcinogenesis at the portal-of-entry is pivotal. In the sensitive rat species, the apparent LOAEC was 6 ppm, and the apparent NOAEC was 2 ppm for nasal cancer. Experimentally, the histopathological NOAEC for nasal effects of FA in rats and monkeys is 1 ppm and the NOAEC for regenerative cell replication is 2 ppm. At these NOAECs, the FA-DNA adducts were less in monkeys than in rats as was the relationship of exogenous/endogenous DNA adducts, which is in line with the assumption that humans should be a less sensitive species. The new studies confirm that local FA-DNA adducts show a highly non-linear relationship with external FA exposures. At ≤ 2 ppm FA, the FA DNA-adducts induced by external exposures comprise a minor portion of the total FA-DNA adducts, which were driven mainly by internal (naturally generated) FA. This is supported by considerations on toxicokinetics, concluding that the intracellular FA concentration increases only slightly, and the intracellular glutathione concentration decreases only slightly in this range and that the homeostasis within the epithelial cells would not be affected. Therefore, the apparent NOAEC of 1 ppm can be considered a mode-of-action based NOAEC for carcinogenic effects at the portal-of-entry.’”

EPA Response: Please see prior responses on this topic (including in Section F.2.3 of these responses above), although EPA notes that the considerations mentioned by the commenter do not necessarily indicate a threshold for formaldehyde’s mutagenic action. As previously described, reviews and studies with no primary data are considered as supplemental materials and tracked in HERO. EPA conducts an independent evaluation of the available evidence.

The IRIS assessment carefully evaluated the temporal and dose-dependence of mutagenicity and cytotoxicity-induced regenerative cell proliferation as key events in the MOA in Section 3.2.5. Ultimately, the available evidence does not support a conclusion that cytotoxicity-driven regenerative cell proliferation is the sole driver of formaldehyde-induced carcinogenicity, nor do the data support that a significant contribution of mutagenicity at lower doses is unlikely.

- Public Comment (American Chemistry Council): “EPA failed to consider Thompson et al. (2020), which provides important data integration related to the MOA for formaldehyde-induced nasal tumors.”
  “The Draft Assessment does not follow the EPA Framework in presenting alternative MOAs and including the empirical support for each. This is directly relevant to the discussion of the cytotoxicity and regenerative hyperplasia MOA for nasal tumors related to inhaled formaldehyde. The Draft Assessment does not reference the Thompson et al. (2020) IPCS MOA analysis for formaldehyde-related nasal tumors that updated the McGregor et al. (2006) assessment. This despite written and oral communications to the EPA from the authors and sponsors. Rather the Draft Assessment acknowledges the MOA as defined by McGregor et al. (2006), as updated by Thompson et al., but without referencing those peer-reviewed publications (see quote below). Furthermore, the Draft Assessment dismisses the MOA, in favor of a mutagenic MOA, without making a quantitative assessment of the cytotoxicity with regenerative hyperplasia MOA as directed by the NAS (2011).”
  “The Draft Assessment does not include a fair evaluation of the most widely accepted MOA for nasal tumor formation related to formaldehyde and does not follow EPA Cancer Guidelines [See also general comments on lack of documentation for MOA]… The exclusion of Thompson et al. (2020) from the Draft Assessment is noteworthy, as Dr. Thompson personally briefed the EPA IRIS staff on the peer-reviewed and published cytotoxicity MOA. This MOA for nasal tumors was recently adopted by the European Chemicals Agency (ECHA) and approved by the 32 countries in the European Union.” [Please see docket for details and supporting information.]
- Public Comment (ToxStrategies): “The following review articles relevant to the MOA of formaldehyde and thus the U.S. EPA risk assessment are not cited anywhere in the Toxicological Review, Assessment Overview, or Supplemental Information. It is unclear if these articles were not captured in U.S. EPA’s literature searches or whether they were captured but intentionally discarded by the U.S. EPA [Thompson et al. 2020; Gentry et al. 2020; Andersen et al. 2019; Thompson et al. 2018].
  “U.S. EPA failed to integrate two highly relevant data streams [studies in ADH5 null mice and measurement of endogenous and exogenous formaldehyde-DNA adducts] into their MOA analysis.”
  “Individually, the studies described above may not paint a coherent MOA for formaldehyde. In totality, however, they tell a remarkably cohesive picture of the likely MOA for formaldehyde-induce nasal tumors. Instead of integrating these data, the U.S. EPA documents are full of speculative discussions of what might theoretically be capable of happening as evidenced by their refusal to develop either a linear or non-linear MOA and instead display networks of plausible mechanistic effects. If there is a study or studies that report that formaldehyde causes, for example, inflammation in the portal of entry and/or systemic tissues, then EPA accepts these effects at face value and further hypothesizes that they could play a meaningful role in an otherwise overly complex intractable MOA while ignoring high-quality molecular data that tell a remarkably coherent study. This is not how risk assessment should be conducted.”
  “Assuming the term “in silico” on page 1-302 was an error and that U.S. EPA instead meant “in vivo” test systems have shown formaldehyde to induce genotoxic or mutagenic effects, this statement too is misleading. As discussed in Thompson et al. (2020), genotoxicity assays conducted in the nasal tissues of rats have reported negative findings for clastogenic and mutagenic markers. As already discussed, ADH5 null mice do not exhibit increases in markers of genotoxicity unless other genes involved in formaldehyde detoxification of DNA repair are also knocked out.”
  “The nasal tumor MOA information provided in the Toxicological Overview is neither clear nor well-constructed. Section 4.2.3. Mode of action information, of the Toxicological Overview is vague and provides no graphical depiction of the hypothesized MOA. Table 34 lists “hypothesized mechanistic events” with no clear indication of the sequence of events. The first mechanistic event is “direct, or presumed direct, genotoxicity and mutagenicity”. The reviewer assumes that U.S. EPA has chosen the word ‘presumed direct’ because much of the evidence for this key event in animals is based on markers of exposure (e.g., DNA adducts and DNA-protein crosslinks) as opposed to markers of effect (e.g., evidence of clastogenic or mutagenic damage).”
  “It is curious that the only real evidence for “direct” genotoxicity and mutagenicity comes from worker and student studies. The use of the term “direct” is highly misleading, as these are not controlled experiments and the workers and students were likely exposed to other agents (chemical or physical) that might increase micronuclei. Notable omissions from Table 35 are Speit et al. (2007) and Zeller et al. (2011).”
  “Table A-22 “Summary of in vivo genotoxicity studies of formaldehyde inhalation exposure in experimental animals” is highly misleading regarding the evidence for in vivo genotoxicity in regions where tumors occur. A total of five studies is listed in the table section “Mutations.” Two of the 5 studies are based on the same underlying bioassay where rats were exposed for 2 years (Recio et al. 1992, Wolf et al. 1995). These studies looked for p53 mutations in tumor tissue, which is not a valid approach for assessing whether genotoxicity is an early initiating event in the MOA. Another study, Kitaeva et al. (1990) is in Russian and appears to have reported genotoxicity in bone marrow cells even though the highest exposure concentration was 1.5 mg/m3, which is not even carcinogenic to the nasal passages of rodents. The fourth positive study is Liu et al. (2009), where male mice were exposed to 0, 2, 20, or 200 mg/m3 formaldehyde for 2 hours and then mated six weeks later. Exposure to 200 mg/m3 was reported to increase heritable mutations in offspring. It should be appreciated that the RD50 for mice is ~5 mg/m3 (see Table A-16 in the Supplemental Information). It is conceivable that exposure to 200 mg/m3 would have depressed respiration much further. Data presented in section A.3 discusses that this reflex bradypnea induces hypothermia in mice (decreasing body temperature by as much as 14 degrees). In addition, U.S. EPA states that reflex bradypnea “also results in decreased blood pO2 and pCO2 and increased blood pH.” It is well known that hypothermia can cause genotoxicity (Tweats et al. 2007). This has no relevance to humans because exposure to irritant gases does not result in extreme levels of heat loss due to the much lower surface area to volume ratio of large mammals compared to small mammals (Gordon et al. 2008). The fifth study in this section, Meng et al. (2010) did not find increases in mutant frequency in nasal tissue following exposure up to 18.5 mg/m3 for 13 weeks. This is the only relevant study in this section of the table.”
  “Table A-22 section “Micronucleus” lists only one study reporting on micronuclei in tissue other than blood or bone marrow. Specifically, Neuss et al. (2010) is listed as negative for micronucleus formation in bronchioalveolar lavage cells. Missing from the table is Speit et al. (2011), which reported no increases in micronucleus formation in rat nasal tissue following 4 weeks of exposure up to ~18 mg/m3 formaldehyde. It is unclear why this study was not included in the table. The vast majority of studies listed in Table A-22 includes either genotoxicity effects beyond the portal of entry or DNA modifications in the nasal and other tissues. These modifications are not measures of heritable gene changes, and thus should not be considered genotoxicity. As already discussed, data in ADH5 null mice indicate that increased formaldehyde DNA adducts are not necessarily genotoxic.”
  “In discussing the role of cell proliferation, U.S. EPA cites evidence for increased cell proliferation ≤2.5 mg/m^3^ as evidence for mitogenic proliferation that might increase cancer risk together with DNA damage. As already noted, these levels can result in squamous metaplasia, i.e., a transition from respiratory to squamous epithelium. As such, comparing the labelling index between treated and control animals is essentially comparing the proliferation rate in two different epithelial types.”
  “On page 1-331, U.S. EPA states that glutaraldehyde cause many of the same effects as formaldehyde (squamous metaplasia, hyperplasia, and inflammation) yet does not increase nasal tumors. U.S. EPA uses this to conclude that increased cell proliferation alone is not sufficient to cause nasal tumors…To my knowledge, the MOA of glutaraldehyde has not been studied as extensively (if at all) as formaldehyde since 2006. As such, the database for glutaraldehyde is insufficient to inform the MOA of formaldehyde.”
  “Table 35 lists ‘cellular mitogenesis in the absence of cytotoxic tissue pathology’ as another hypothesized mechanistic event. In the column titled ‘experimental evidence pertinent to mechanistic event’ there is a bullet stating that there is clear evidence for increased URT ‘cell proliferation under conditions also resulting in tissue pathology’ at ≥4 mg/m^3^. Unless this bullet includes a typo, it is unclear how that bullet supports the hypothesized event. The next bullet states that there is ‘suggestive evidence’ for increased URT ‘cell proliferation under conditions not clearly causing tissue pathology’ <4 mg/m^3^. This bullet does support the hypothesized key event; however, note the overall weak terminology such as ‘suggestive evidence’ of cell proliferation ‘not clearly causing’ pathology. This language is weak and its purpose seems to be to establish cell proliferation at exposure concentrations more relevant to human exposure levels than the higher concentrations clearly associated with increasing cell proliferation and tumors in rodents.”
  “The U.S. EPA should revise its assessment such that the presence of DNA-protein crosslinks and formaldehyde-DNA adducts is not synonymous with genotoxicity.”
  “Much of the text on pages 1-315 to 1-320 includes discussion about the accumulation of DNA-protein crosslinks. This accumulation is discussed in the context of Leng et al. (2019) who reported that exposure to ≤0.3 ppm formaldehyde for 28 days did not result in the detection of exogenous formaldehyde-DNA adducts. U.S. EPA appears to be speculating that longer exposure durations to low concentrations might increase adducts. If accumulation were true, then one might expect that the constant biological production of endogenous formaldehyde would increase the levels of endogenous adducts over time. I am not aware of any articles that have demonstrated this. Considering that U.S EPA believes formaldehyde adducts are pro-mutagenic but also acknowledge that nasal tumors in rodents are exceedingly rare, it would seem that endogenous adducts do not accumulate over time and nor would any exogenous adducts formed from exposure to ≤0.3 ppm formaldehyde accumulate over time. The U.S. EPA also fails to consider that evidence for accumulation of exogenous adducts over time might be due, in part, to remodeling to squamous epithelium where the superficial cell layers are dead yet likely accumulate exogenous adducts as exposure duration increases.” [Please see docket for details and supporting information.]

EPA Response (to both public comments above): The MOA analyses and decisions presented in the external review draft are retained in the revised assessment. The NASEM committee had no Tier 1 recommendations on this topic and EPA has addressed the panel findings and other comments on this topic. As noted previously, EPA conducts an independent analysis of the available articles, so the stance of EPA on the impact and utility of the papers to inform assessment conclusions can differ from the views and conclusions expressed by the study authors. Further, reviews and studies with no primary data are considered as supplemental materials and tracked in HERO.

The IRIS assessment carefully evaluated the temporal and dose-dependence of key events in the mutagenicity and cytotoxicity-induced regenerative cell proliferation MOAs. During this review, several lines of evidence were identified to support increases in genotoxicity markers that preceded other mechanistic changes, and which sometimes occurred at lower exposure levels than those known to cause cytotoxicity (see Section 3.2.5). This included changes in exposed human workers as well as in several experimental animal species, all strongly supporting a role for direct DNA damage leading to mutagenicity in formaldehyde exposure-induced URT carcinogenesis.

The analyses also revealed large temporal and spatial (location in the nasal passages) variability in the available data on cell proliferation in experimental animals (see characterization of uncertainty and variability in cell replication rates in Appendix D.2.2, noting that direct evidence in humans is lacking). This variability complicates interpretations regarding a threshold dose for this mechanism. This uncertainty is further illustrated in the IRIS assessment review of the BBDR modeling in Appendix D.2.2. EPA estimated that the mutagenic component in the BBDR modeling by Conolly et al. (2003) contributes between 2% and 80% of the predicted probability of tumor incidence in the low-dose region, and between 58%–74% of the predicted probability of tumor incidence in the high-dose range of exposures where tumors were observed, depending on whether a J-shape or hockey-stick shape is assumed for the dose response for cell proliferation.

Overall, the available evidence does not support a conclusion that cytotoxicity-driven regenerative cell proliferation is the sole driver of formaldehyde-induced carcinogenicity, nor do the data support that a significant contribution of mutagenicity at lower doses is unlikely.

- Public Comment (American Chemistry Council): “The 2005 Guidelines provide that while a linear extrapolation would generally be the default for DNA reactive chemicals, a threshold approach would be allowed given sufficient evidence. The descriptor “Not likely to be carcinogenic to humans at concentrations that do not cause nasal tumors in rodents” should be used, as should a threshold approach for deriving a toxicity value.”
  “Animal evidence clearly demonstrate a threshold for induction of squamous cell carcinoma, which corresponds to concentrations above where cell proliferation is induced (Monticello et al. 1991; Connolly et al. 2002 as cited in BfR 2006; Swenberg et al. 1980; Kerns et al. 1983; Monticello et al. 1996).”
  “EPA grossly misinterpreted the work of Dr. Marsh, which the 2022 Draft Assessment cites throughout…Of the Marsh et al. papers that were not cited in the 2022 Draft Assessment, EPA omitted the following important studies… [Marsh et al. 2019, Marsh et al. 2014, Marsh and Youk 2004]…The 2022 Draft Assessment also misinterprets and misrepresents several of the Marsh et al. papers that it cites. [Marsh et al. 1996, Marsh et al. 2007b, Marsh and Youk 2005, Marsh et al. 2007, Mart et al. 2016, Marsh et al. 2002].”
  “EPA’s Cancer Guidelines emphasize ‘a critical analysis of all the available information that is relevant to assessing the carcinogenic risk,’ rather than reliance on default options as the starting point. A nonlinear approach should be utilized when, as in the case of formaldehyde, ‘there are sufficient data to ascertain the mode of action and conclude that it is not linear at low doses and the agent does not demonstrate mutagenic or other activity consistent with linearity at low doses.’ The Cancer Guidelines also stress the importance of relying upon, ‘common sense reasonable applications of assumptions and policy, and transparency…to avoid unrealistically high [risk] estimates.’” [Please see docket for details and supporting information.]

EPA Response: EPA judged that the evidence is sufficient to conclude that a mutagenic MOA of formaldehyde is operative in formaldehyde-induced nasopharyngeal carcinogenicity, and this was supported by the NASEM peer review (e.g., “While there is uncertainty in the degree to which nonmutagenic processes may also contribute to the carcinogenic activity of formaldehyde inhalation at the point-of-entry tissues, there is sufficient evidence to support the assumption that a mutagenic MOA is involved in the carcinogenesis of formaldehyde in the upper aerodigestive tract in humans.”). The 2005 Cancer Guidelines (U.S. EPA, 2005) make it clear that when a mutagenic MOA is operative, linear extrapolation is used to derive the IUR and ADAFs are applied to develop risk estimates. EPA notes that reviews and studies with no primary data are considered as supplemental materials and tracked in HERO.

The IRIS assessment includes hundreds of pages evaluating and considering the mechanistic evidence in accordance with EPA’s cancer MOA framework. This includes extensive documentation of the evaluations necessary to scientifically support the nasal cancer MOA conclusions drawn, which were supported by the NASEM external peer review. The assertions that the nasal cancer MOA is limited to cytotoxicity/regenerative proliferation and that mutagenicity is not supported at lower doses are not sustained by the available scientific evidence. Specifically, evaluations of the mechanistic evidence relevant to the nasal cancer MOA are documented in Appendix B.3 for studies of inflammatory changes, tissue injury, and cellular proliferation, and in Appendix C.3 for genotoxicity studies. The extensive nasal cancer MOA information is synthesized together according to the EPA cancer guidelines in Section 3.2.5. In addition, Appendix C.1 describes the available toxicokinetic data and dosimetry modeling, and Appendix D.2 documents the strengths and uncertainties of those models for use in describing nasal cancer risk, with the summary application of those evaluations to deriving an inhalation unit risk described in Section 5.2.1.

A key consideration in applying the 2005 EPA cancer guidelines is the strong evidence supporting that formaldehyde is both a direct- as well as an indirect-acting mutagen. However, there is no clear demarcation in dose that separates these actions (see EPA response to the prior public comment above on the nasal cancer MOA), a conclusion supported by the extensive analyses in the IRIS assessment.

The IRIS assessment is in line with both the general and specific recommendation in the EPA cancer guidelines. As noted in the assessment and in the response to the prior MOA comment above, formaldehyde is shown to have direct mutagenic action. As recommended in Appendix A of the cancer guidelines, “… the linear approach is used … for example, when a conclusion is made that an agent directly causes alterations in DNA, a kind of interaction that not only theoretically requires one reaction but also is likely to be additive to ongoing, spontaneous gene mutation.” In the case of formaldehyde, the point in the cancer guidelines regarding additivity to background is particularly relevant because of the highly variable endogenous levels in humans.

- Public Comment (University of North Carolina at Chapel Hill): “The EPA IRIS Draft recognized the potentially important role of epigenetic regulation in MOA of nasal tumor, yet further data from animal and human studies are needed…I appreciate that the EPA IRIS Draft recognized the potential important role of epigenetic regulation in the MOA of formaldehyde by stating ‘DNA methylation and histone modification can promote carcinogenesis through steric regulation of enhancer/promoter binding and transcription factor-DNA association, thereby affecting gene transcription’ and ‘suggesting that these epigenetic effects may play a causal role in human URT cancer formation.’ However, no studies have exclusively examined histone PTM and DNA methylation in formaldehyde-exposed animals or human. Therefore, the data used in the IRIS Draft were largely limited to cultured cells or results based on N6-Formyllysine that is not a highly relevant biomarker of formaldehyde exposure and epigenetic regulation, which represents a significant data gap in understanding MOA of formaldehyde-induced nasal tumor.” “Recommendation: Further studies (animal and human) are needed to improve understanding of the role of mutation and epigenetic factors, including histone modification and DNA methylation, contributing to the cytotoxicity with regenerative hyperplasia MOA.” [Please see docket for details and supporting information.]

EPA Response: EPA appreciates and agrees with this future recommendation that additional studies on the topic of epigenetic regulation would be informative.

- Public Comment (Cardno ChemRisk [now Stantec]): “Page 159, lines 3-11: Comment 1: Marsh et al. (1996) concluded that the NCI cohort formaldehyde exposure estimates may be inflated in Plant 1 plant of the NCI cohort study (Plant 1 in Wallingford, CT), where many of the NPC cases occurred, all of which were associated with the highest exposure categories. The 2022 draft interpretation suggests that all exposures in the NCI study, which includes 10 plants, would have been impacted by exposures in Plant 1, and thus that the true risk would have been overpredicted in the entire study. This is a serious misrepresentation of the Marsh et al. (1996) findings that were limited to Plant 1.”
  “Page 1-209, lines 1-11: Comment 2: This is the source of the serious misrepresentation noted in Comment 1 above which could potentially mislead the reader to believe that all risks were understated in the NCI cohort study.”
  “Page 1-209, lines 32-39, Page 210, lines 1-3: Comment 3: The 2022 IRIS draft fails to consider Table 6 in Marsh et al 2007b, which reported results based on the interaction terms used in the case-control study modeling. This showed that when comparing workers with formaldehyde exposure only to workers with neither formaldehyde nor silversmithing or other metal work exposure there was no elevation in the risk of NPC. In contrast, when comparing workers with silversmithing or other metal work to workers with only formaldehyde exposure the odds ratio for NPC was 13.37. These findings suggest that co-exposures to silversmithing or other metal work, which include risk factors for NPC and other upper respiratory system cancers, played a major role on the NPC findings that were unique to Plant 1 in the NCI study. These findings were essentially disregarded by the 2022 IRIS draft.”
  “Marsh et al. (2007b) also reported but did not show results of interaction models for the category all other pharyngeal cancers (AOPC) that generally produced more robust risk estimates due to the larger number of cases. For example, the conventional baseline model further adjusted for year of hire revealed a 4.32-fold increased risk for subjects with silversmithing or other metal work only, whereas subjects exposed only to formaldehyde had no elevated risk of AOPC. Here subjects with both exposure factors had a decreased risk for AOPC due to the heavy influence of subjects with formaldehyde exposure only (10 of 16 cases).” “Pages 1-210; lines 3-16: Comment 4: EPA’s argument that the results for NPC in the NCI cohort consistently show an association between formaldehyde and NPC risk is not supported by the data in Table 2 of the Marsh and Youk (2005) paper. Specifically, Table 2 shows that the SMR based on local rates for NPC among Plant 1 workers was 7.39 and statistically significant based on 6 of the 10 total NPC deaths in the NCI cohort study. In stark contrast, the corresponding SMR for workers in the remaining nine plants in the NCI study was 0.98 -- essentially a null value. This finding highlights the inconsistency of the results in the NCI cohort study and shows clearly that Plant 1 was unique with respect to non-formaldehyde risk factors for NPC. In the Marsh et al. (2007) case-control study discussed in Comment 3, it was concluded that the unique and profound findings for NPC in Plant 1 were likely due to risk factors associated with exposures in previous or post-Plant 1 jobs in the silversmithing or other metalworking industry. The authors stated “the results of our nested case-control study suggest that the large NPC mortality excess in the Wallingford cohort (Plant 1) may not be due to formaldehyde exposure but rather reflects the influence of external employment in the ferrous and nonferrous metal industries of the local area that entailed possible exposures to several suspected risk factors for upper respiratory system cancer (e.g., sulfuric acid mists, mineral acid, metal dusts and heat)”. This association reported in the Marsh et al. (2007) publication was given no consideration in the 2022 IRIS draft.”
  “Page 1-210, lines 34-37: Comment 5: While no specific Marsh citations were stated in this conclusion, it should be noted that this conclusion is not consistent with that reached by Marsh and colleagues in several papers, most recently Marsh et al. (2016). In this second reanalysis of the NCI cohort data Marsh et al. concluded “Our updated analysis provided little or no evidence to support NCI’s suggestion of a persistent association between formaldehyde exposure and mortality from NPC. NCI’s suggestion continues to be driven heavily by anomalous findings in one study plant (Plant 1).” This and earlier Marsh et al. reanalyses of the NCI formaldehyde cohort demonstrated that the results of the NCI study for NPC mortality were driven heavily by the results in Plant 1 which ultimately included six of 11 NPC cases. As noted in the above comments, Marsh et al. (2007) found that the NPC excess unique to Plant 1 was likely due to external exposures in the ferrous and nonferrous metal industries of the local area.”
  “Page 1-239, Table 1-33: Comment 6: The Marsh et al. (2007a) citation is incorrectly stated in the reference list. This actually should be what is stated as 2007b.”
  “Page 1-254, Lines 1-8: Comment 7: The 2022 IRIS draft cites only SMRs based on US rates, whereas the Marsh et al. (2007b) article also provided the more valid SMRs based on local county population rates. In this case, the local rate based SMRs were lower than those cited by IRIS.”
  “Page 1-254, lines 15-19: Comment 8: This is a confusing and incorrect statement because the Marsh et al. (2002) paper did not present results for oropharyngeal / hypopharyngeal cancer in relation to years of formaldehyde exposure. Results were presented for the category “all pharyngeal cancer” and the category “NPC only.” It appears that EPA re-calculated SMRs using data from the Marsh et al. (2002) paper. As noted below, there may be errors in EPA’s calculations of the confidence intervals.”
  “Page 1-254, lines 29-34: Comment 9: Same response as comment 8.”
  “Page 1-255, lines 3-5: Comment 10: First, this reference should be Marsh et al (2007b). Second, the results shown for hypopharyngeal and pharyngeal cancer unspecified are reversed. Third, no mention is made of the local rate-based SMRs for these categories, which in every case were lower than those based on US rates.”
  “Page 1-255; lines 3-5: Comment 11: The SMRs and CIs for Marsh et al. (2002) ‘Exposure to formaldehyde >0.2ppm’ were “calculated using the Mid-P method” by EPA, but could not be replicated in calculations using the specifications in the table footnotes; specifically, the CIs calculated were different than I calculated using the stated methods. Per my calculations, the Level 1 SMR and 95% CI should be 1.51 (0.61-3.13) and the Level 2 SMR and 95% CI should be 2.01 (0.98-3.68). As a result, the Level 2 95% CI would no longer be considered statistically significant as our calculated lower bound is less than one. These errors in calculations thus could have affected how EPA interpreted Marsh et al. (2007b); these calculations should be corrected and the updated conclusions incorporated accordingly.”

EPA Response: EPA has reviewed the cancer evidence synthesis and dose-response sections (including the calculations) and incorporated several typographical corrections. Importantly, however, the revised assessment retains the strong conclusions regarding NPC cancer hazard and risk (Sections 3.2.5 and 5.2), as supported by the consensus peer review panel (see findings above). The NASEM committee did not have Tier 1 recommendations on this topic and EPA has addressed the other committee comments on this topic. In addition, the conclusions on cancer by other federal and international agencies are summarized in Appendix G. Specifically, the hazard conclusion for human carcinogenicity in the IRIS assessment is consistent with those drawn by other expert review panels. Formaldehyde was classified as a known carcinogen by the (NTP, 2011a) and a Group 1 carcinogen by (IARC, 2006, 2012), both based on evidence for nasal cancers in humans and animals and myeloid leukemia in humans, with supporting data on mechanisms of carcinogenesis. In addition, an expert committee convened by the NAS confirmed the conclusions of the NTP 12^th^ Report on Carcinogens (RoC) and conducted an independent review of the literature through 2013, concluding that formaldehyde is a known carcinogen.

Note that the peer review also supported the methods used to evaluate and synthesize the available cancer studies, including the studies by Marsh et al. A few specific points are included below for clarity. Marsh et al. (2002) stated “our estimates of median AIE to formaldehyde with and without co-exposure to particulates are more than ten times lower than corresponding values estimated for the same Wallingford workers in the NCI study (Blair et al., 1986).” In discussion the potential for information bias, EPA noted that systematic measurement error could bias results if exposures were overestimated by NCI. EPA stated that “If this were true, then the same amount of observed risk in Beane Freeman et al. (2013) would be apportioned to one-tenth the same exposure, which would yield an exposure-response 10-fold greater in magnitude. The claim by Marsh et al. (2007, 2002) suggests a one-sided uncertainty in the exposure-response reported by Beane Freeman et al. (2013), which may be 10 times more potent than reported.” EPA acknowledged that there could have been exposure measurement error as Marsh et al. suggested and EPA noted that overestimating exposure would have diminished the apparent exposure-response.

- Public Comment (ScitoVation): “I believe there is an issue with the interpretation of a manuscript that I was the senior author… the p53 point mutations observed in the Recio et al. (1992) study, which EPA cites as evidence of a formaldehyde-induced initiating event in their draft document, is not plausible for several reasons…There is no pathway for DPC to cause the point mutations observed exclusively at GC base pairs. Genotoxicity observed in respiratory tissues are not measures of mutagenic events, particularly point mutations: genotoxicity [does not equal] mutagen[i]city. There is no evidence to support a temporal nature of a mutagenic carcinogen as outlined by EPA. Finally, as determined by NTP, there is no data to support a role for p53 in formaldehyde-induced neoplasia. Although I recognize that p53 mutations are considered hallmarks of cancer, the concern I have is the misrepresentation in your review of the Recio et al., 1992 manuscript indicating that these late occurring mutations are caused by formaldehyde induced DNA lesions. With the lack of any data to support a mutagenic event prior to tumor outcome in the target tissues, I conclude that the p53 mutations observed in SCC from formaldehyde exposed rats are late occurring passenger mutations resulting from known genome instability that occurs in cancers, are not formaldehyde-induced point mutations and do not support a mutagenic mode-of-action for tumor outcomes from formaldehyde exposed rats.”

EPA Response: The MOA conclusion that mutagenicity contributes to formaldehyde inhalation-induced nasal cancers is retained in the revised assessment, consistent with the consensus peer review findings (above). EPA has addressed all panel comments on this topic. As noted previously, EPA conducts an independent analysis of the available articles, so the stance of EPA on the impact and utility of the papers to inform assessment conclusions can differ from the views and conclusions expressed by the study authors. As discussed in prior responses to related public comments, the available evidence does not support a conclusion that cytotoxicity-driven regenerative cell proliferation is the sole driver of formaldehyde-induced nasal carcinogenicity, nor do the data support that a significant contribution of mutagenicity at lower doses is unlikely.

- Public Comment (Natural Resources Defense Council): “NRDC supports the EPA conclusion that – with its highest rating of confidence - “evidence demonstrates” a causal link between formaldehyde exposure and three cancer endpoints, nasopharyngeal cancer (NPC), myeloid leukemia and sinonasal cancer (SNC). NRDC agrees that this is consistent with the scientific evidence.”
  “The 2010 IRIS report that “the associations between myeloid leukemia and formaldehyde exposure are positive and consistent” and that “human epidemiological evidence is sufficient to conclude a causal association between formaldehyde exposure and nasopharyngeal cancer, nasal and paranasal cancer … [and] myeloid leukemia.” There are no post-2010 data that casts doubt upon that connection. The risk of this endpoint should be included in EPA’s overall cancer risk.”
  “NRDC supports EPA’s evaluation that the scientific evidence demonstrates that exposure to formaldehyde causes myeloid leukemia. Although EPA has “low” confidence in its risk estimate for myeloid leukemia (compared to “medium” confidence in its NPC-based risk figure) EPA could increase scientific confidence in the data by leveraging the meta-analysis of Zhang et al 2009 (discussed above) to support the risk estimate. Use of the meta-analysis can increase the precision of an effect estimate, by basing the estimate on a larger number of studies, and can also be used to quantify effects across sufficiently homogeneous studies. Meta-analyses frequently underpin Health Impact Assessments (HIA) and cost-benefit analyses (CBA) of interventions, such as policies to reduce air pollution. Meta-analyses can provide important opportunities when synthesizing study results to strengthen hazard evaluations, and should be used by EPA with appropriate considerations of study quality etc.”
  “Zhang et al 2009 propose a biologically plausible mechanism for leukemia as follows: “formaldehyde may act on bone marrow directly or, alternatively, may cause leukemia by damaging the hematopoietic stem or early progenitor cells that are located in the circulating blood or nasal passages, which then travel to the bone marrow and become leukemic stem cells.” Where the EPA Draft states that, “No MOA has been established to explain how formaldehyde inhalation can cause myeloid leukemia without systemic distribution…” (p. 54) this statement - and sentiment- should be corrected to note the proposed mechanism of Zhang et al 2009.”

EPA Response: The conclusion regarding lack of a MOA explaining formaldehyde inhalation-induced myeloid leukemia has been retained in the revised assessment (see Section 3.3.3). As noted previously, EPA conducts an independent analysis of the available articles, so the stance of EPA on the impact and utility of the papers to inform assessment conclusions can differ from the views and conclusions expressed by the study authors.

#### Evidence Syntheses and Synthesis Judgments for Lymphohematopoietic Cancers

##### Peer Review Findings and Comments

- Finding (9): With respect to cancer hazard identification for lymphohematopoietic cancer in humans exposed to formaldehyde, EPA was responsive to previous recommendations of the NRC (2011, 2014) and focused on the most specific diagnoses of myeloid leukemia, lymphatic leukemia, multiple myeloma, and Hodgkin lymphoma.
- Finding (10): With respect to cancer hazard identification for lymphohematopoietic cancers in humans exposed to formaldehyde, EPA used appropriate methods to synthesize the current state of the science and presents conclusions regarding the hazard identification analysis that accord with its framework and criteria, and are based on expert judgment with the support of the available scientific evidence.
- Tier 2 Suggested Revision (Recommendation 5.3): To add clarity, EPA should, in the captions of figures displaying the findings of epidemiological studies for the different cancers, provide references to the numbers of the tables that describe the confidence in each study (low, medium, or high) and “results” (high vs. medium confidence, as presented in Figure 1-38).

EPA Response to Tier 2 Suggested Revision 5.3: References to the associated tables of epidemiological results for each cancer have been added to the captions of the cancer-specific figures.

- Finding (11): With respect to cancer hazard identification for lymphohematopoietic cancers in animals exposed to formaldehyde, EPA used its state-of-practice methods to synthesize the current state of the science, and presents conclusions regarding the hazard identification analysis based on its expert judgment with the support of the available scientific evidence.

EPA Response to Finding 11: While no response is necessary, EPA is clarifying the following misstatement from the peer review report: “One chronic-duration inhalation study that reported detailed information on formaldehyde-induced leukemia or lymphoma in rodents (Battelle, 1982) was deemed indeterminate because its results remain unpublished.” This study was not deemed indeterminate; it was actually deemed a high confidence study in the external draft assessment (now classified as a medium confidence study in the revised assessment, for the reasons described above). The animal evidence overall was deemed indeterminate due to the limitations in the available animal evidence that are discussed in the evidence synthesis. The revised presentation of the studies and conclusions in this synthesis section should help to eliminate such misperceptions.

- Finding (12): With respect to evidence on MOA for lymphohematopoietic cancers, EPA used its state-of-practice methods to synthesize the knowledge. The presentation of conclusions regarding the mechanistic evidence and how it supports hazard identification is appropriate.
- Finding (13): EPA presents an overall clear and succinct evidence integration summary for effects of formaldehyde inhalation on lymphohematopoietic cancers. EPA followed its state of practice for evidence integration at the time the 2022 Draft Assessment was being developed in evaluating studies of cancer outcomes in humans and animals, as well as mechanistic evidence, where available.

##### Related Public Comments

- Public Comment (American Chemistry Council): “The opaque and inconsistent process of evidence integration in the 2022 Draft Assessment is exemplified in EPA’s treatment of the evidence for nasopharyngeal cancers (NPCs) relative to lymphohematopoietic malignancies. In both cases, EPA concluded that the ‘evidence demonstrates’ that formaldehyde inhalation causes NPCs and myeloid leukemia, ‘given appropriate exposure circumstances.’ However, the body of evidence for these two cancers are quite different and based on EPA’s own criteria, should not have the same hazard determination…In the case of NPCs, nasal tumors occur in animals and there are plausible MOAs that have supporting evidence (primarily, cytotoxicity and regenerative proliferation) to support the epidemiological findings. In contrast, myeloid leukemia has no positive animal evidence nor biologically plausible MOA.”
  “EPA’s 2005 Guidelines indicate that meta-analysis can follow systematic review and can be helpful when varying degrees of risk or conflicting results are present. A meta-analysis by Mundt et al. (2021) indicates the descriptor “Inadequate information to assess carcinogenic potential” should be used until a meta-analysis that separately analyzes AML (with control for tobacco smoking) and CML is conducted by EPA solely under its 2005 Guidelines.”
  “The experimental evidence in animals on formaldehyde inhalation was incorrectly assessed in the Draft Assessment, leading to an inaccurate determination that ‘the evidence available from animal studies is considered indeterminate for drawing conclusions as to whether or not formaldehyde exposure might cause leukemia or lymphoma.’ Formaldehyde is one of the most-studied chemicals in the world. Reflecting this, eleven cancer bioassays have been performed with formaldehyde (that have recently been reviewed by Thompson et al., 2020), via the inhalation route: seven in rats, two in mice, and two in hamsters. A complete animal experimental database in laboratory animals is often considered to consist of chronic bioassays in two species, which clearly formaldehyde exceeds. If the formaldehyde cancer bioassay database is considered indeterminate, then virtually no experimental database can meet the bar set in the Draft Assessment. We disagree with the low rating of the overall study quality of the database in the Draft Assessment. Notably the Draft Assessment rated one rat cancer study (Table 1-65) and one mouse cancer study as “high confidence” studies, clearly meeting the EPA definition of a complete database for assessing formaldehyde carcinogenicity. Thus, it is unclear why his database was considered “indeterminant” in the Draft Assessment. Neither of the two high confidence studies identified a treatment-related increase in leukemia; their exclusion from integration into the assessment of leukemogenic potential prevents the Draft’s conclusions from reflecting best available science.”
  “In synthesizing the results of the epidemiology studies, EPA emphasized consistency, magnitude of effects, and dose-response gradients. For example, the EPA reported ‘consistent increases in risk across a set of high and medium confidence, independent studies with varied study designs and populations.’ The estimates of relative risk of myeloid leukemia, however, were not consistent within or between studies in relation to various formaldehyde exposure metrics…A conclusion of consistent associations between formaldehyde exposure and myeloid leukemia is not scientifically justifiable when the observed associations between formaldehyde measures and myeloid leukemia differ according to exposure metrics between studies (that is, consistency is not met when one study reports an association with peak exposure but not cumulative exposure, while another study reports an association with cumulative exposure but not peak exposure).”
  “The scientific evidence does not support EPA’s conclusion that ‘evidence demonstrates’ formaldehyde causes myeloid leukemia. In the 2022 Draft assessment, EPA concluded that ‘the evidence demonstrates that formaldehyde inhalation causes myeloid leukemia in humans given appropriate exposure circumstances’90 This conclusion mirrors the conclusion in the 2010 Draft Assessment. In its revised assessment of lymphohematopoietic (LHP) malignancies, EPA no longer categorizes LHPs as one large group, as recommended by NASEM (2011). EPA, however, continues to lump two distinct cancers -- acute myeloid leukemia (AML) and chronic myeloid leukemia (CML), into myeloid leukemia.”
  “The 2022 Draft Assessment concludes that the human evidence for myeloid leukemia is ‘robust’ based on ‘consistent increases in risk across a set of high and medium confidence… studies…strong associations…and…temporal relationship[s] consistent with causality.’50 However, setting aside the inappropriate grouping of acute myeloid leukemia (AML) and chronic myeloid leukemia (CML), the body of epidemiological evidence on myeloid leukemia does not provide ‘robust evidence’ of an association – it is neither consistent nor strong. Specifically, epidemiological studies of occupational groups historically highly exposed to formaldehyde generally do not demonstrate statistically significantly increased rates of myeloid leukemia or more specifically AML and CML:
  1. No statistically significant excess risk above background rates of myeloid leukemia is reported in the three myeloid leukemia studies rated as having “effect estimates classified with high confidence” (Hauptmann et al., 2009; Beane Freeman et al., 2009; Meyers et al. 2013).
  2. Results from studies with as high or higher quality observed no significant increases in AML, CML, or myeloid leukemia (Saberi Hosnijeh et al. 2013, Talibov et al. 2014, Checkoway et al. 2015).
  3. Results do not indicate consistent excesses across exposure measures in the studies rated “high confidence” (Hauptmann et al., 2009; Beane Freeman et al., 2009; Myers et al. 2013).
  Overall, there is no ‘reasonable confidence that alternative explanations’ (i.e., chance) can be ruled out.”
  “Given that EPA acknowledges in the 2022 Draft Assessment that there are no known MOAs for formaldehyde and lymphohematopoietic malignancies, EPA should have deprioritized these malignancies for assessment.”
  “The Draft Assessment inappropriately combines myeloid and other/unspecified leukemias together into one class which it then refers to as “myeloid leukemia (p. 2-87) contrary to the NAS (2011) recommendation against combining incidence of different leukemia types.”
  “NASEM has consistently recommended improvements to the evidence integration process, including its transparency. Evidence integration should focus on outcomes or endpoints with robust evidence and fully consider study quality. This should include consideration of MOA. As detailed further below, the 2022 draft does not fully meet this recommendation, particularly with respect to lymphohematopoietic malignancies. EPA concluded ‘evidence demonstrates’ that formaldehyde inhalation causes myeloid leukemia in humans, despite the weak human evidence, lack of evidence in animal studies, and lack of a biologically plausible MOA.”
  “There is compelling evidence that inhaled formaldehyde is 1) not systemically distributed at ≤15 ppm, precluding a direct mutagenic MOA; and 2) not leukemogenic in animal models, including transgenic models designed to be sensitive for detecting leukemogenic effects. The Draft Assessment, however, sets aside the evidence that does not support a leukemogenic effect. Rather, the Draft Assessment concludes that formaldehyde is a known human leukemogen, based solely on a non-statistically significant numerical association inconsistently observed in epidemiology studies. This is not reflective of data integration, causal determination based on weight of evidence, or sound science.”
  “There is no established plausible mode of action for myeloid leukemias.
  ○ EPA continues to rely on flawed studies purportedly demonstrating an MOA.
  ○ EPA’s speculations on potential MOAs for myeloid leukemia lack evidence and therefore biological plausibility.
  ○ EPA fails to consider Gentry et al. (2020) in assessing the biological plausibility of a causal association between inhalation of formaldehyde and myeloid leukemia”
  “Failure to fully integrate evidence in this manner, along with numerous other limitations in EPA’s synthesis of the epidemiological evidence, are discussed in detail in the sections that follow. They can be broadly summarized as follows:
  ○ EPA lumps together myeloid leukemias, failing to differentiate between AML and CML, which have very distinct genetics and risk factors.
  ○ EPA fails to truly weigh and integrate the available evidence: it inappropriately downgrades and dismisses important re-analyses and studies, including Checkoway et al. (2015), which are highly informative regarding formaldehyde and LHP malignancies.
  ○ EPA raises up flawed studies such as Hauptmann et al (2009).
  ○ EPA mischaracterizes and overemphasizes risk estimates for purported peak exposure metrics relative to cumulative exposure metrics, which are consistently null.”
  “Since the NAS (2011) review, more definitive data on the lack of systemic distribution of inhaled formaldehyde have become available (Lu et al., 2011; Moeller et al. 2011; Edrissi et al. 2013, 2017; Yu et al. 2015; Lai et al., 2016; Leng et al., 2019). It is noteworthy that the more recently published peer-reviewed literature provides further support for the conclusions reached by the NAS (2011) that there is a lack of causal evidence Such evidence on causality, or the lack thereof, was recently assessed by Gentry et al. (2020) using the IPCS MOA framework. They concluded that LHPs are highly unlikely to be directly related to inhalation of formaldehyde.”
  “The Draft Assessment maintains problematic conclusions on systemic genotoxicity/mutagenicity in circulating blood cells. The Draft Assessment continues to conclude that a mutagenic MOA is operable for systemic effects, despite conclusive evidence that formaldehyde is not systemically distributed after inhalation, at environmentally relevant concentrations. It is hard to understand why the EPA continues to conclude that a potential biomarker of a mutagenic effect on circulating blood cells, that is not dose-responsive, supports a linear low-dose leukemogenic response, when EPA has previously and repeatedly been advised this approach is problematic.”
  “As discussed in these comments, EPA relies heavily on just a few flawed studies (Zhang et al. 2009, 2010; Lan et al. 2015) which ‘reported effects on myeloid progenitor cells cultured from peripheral blood of exposed workers compared to cells cultured from controls without occupational formaldehyde exposure.’^58^ These studies have since been refuted in the literature (Mundt et al., 2017.”
  “Furthermore, a direct genotoxic effect on the bone marrow, resulting in an impact on circulating cells, has been all but disproved by several studies published after Zhang et al.’s (2010) initial study including Lu et al. 2011, Moeller et al. 2011, Yu et al. 2015, and Lai et al. 2016. These studies show that due to the reactive nature of formaldehyde, exogenous formaldehyde is not able to move beyond “the portal of entry” (Mundt et al. 2017).”
  “Furthermore, there is ample literature examining whether formaldehyde might cause mutations leading to cancer in blood progenitor cells. Drs. Albertini and Kaden note in their comment on the 2022 Draft Assessment that EPA failed to include two of their papers:
  ○ Albertini RJ, Kaden DA. 2016. Do chromosome changes in blood cells implicate formaldehyde as a leukemogen? Critical Reviews in Toxicology, 47(2): 145–184.27685449
  ○ Albertini RJ, Kaden DA. 2020. Mutagenicity monitoring in humans: global versus specific origin of mutations. Mutation Research/Reviews in Mutation Research, 786: 108341.33339577 ”
  “EPA mistakenly assumes that biomarkers of exposure (or even effect) in circulating blood cells are the same as genotoxicity in target cells.”
  “The Draft Assessment still considers indirect biomarkers of systemic genotoxicity as evidence supporting a genotoxic MOA. The Draft Assessment uses this mechanism to support the hypothesis of cytogenetic effects in circulating blood cells and calculate a linear IUR for leukemia in the absence of any dose-response observations for leukemia or demonstration of in vivo genotoxicity. The approach taken in the Draft Assessment clearly does not follow or adequately address the NAS comments above.”
  “For example, in the highly influential National Cancer Institute (NCI) cohort study (Beane-Freeman et al. 2009), the strength and specificity of the exposure-response associations varied considerably over the period in which the cohort was followed. In addition, the reliance on the peak-exposure metric to determine causality in that study rather than the more conventional dose metric of cumulative exposure should be further justified, particularly in the absence of established modes of action.^44^”
  “… the draft concludes that that the strength of the human evidence for myeloid leukemia is “robust” based on “several” studies with consistent findings. EPA’s conclusion is based largely on the Beane Freeman analyses of the NCI cohort (pg. 1-542). EPA did not appropriately integrate apparently conflicting findings in the older epidemiological studies (Hauptman et al. (2009) funeral workers study, Beane Freeman et al. (2009) analysis of the NCI cohort) with the analyses published more recently, which demonstrate no excess in cancer risk (e.g., Checkoway et al. (2015) re-analysis of the NCI cohort). EPA should re-examine its evaluations of study confidence (and risk of bias, especially including statistical analyses) and more fully integrate and interpret the earlier studies in the context of the broader body of more informative and updated studies.” [Please see docket for details and supporting information.]
- Public Comment (Louisiana Chemical Association): “The classification of ‘evidence demonstrates’ that formaldehyde causes myeloid leukemia is not supported and should be reevaluated based on the growing amount of information which argues against a causal association. Based on EPA guidelines (Table 8 of EPA, 2022a), the classification of ‘evidence suggests’ is more appropriate given the conflicting and inconsistent findings in human epidemiological studies, the indications of chance, bias and confounders in key positive epidemiological studies, the consistent lack of statistically significant associations, negative animal studies, and the lack of mechanistic evidence supporting a mode of action.” [Please see docket for details and supporting information.]

EPA Response (to both comments above): The revised assessment retains the conclusion of evidence demonstrates for myeloid leukemia. This conclusion was supported by the consensus peer review panel (finding 10) in their response to EPA’s charge question on the topic: “With respect to cancer hazard identification for lymphohematopoietic cancers in humans exposed to formaldehyde, EPA used appropriate methods to synthesize the current state of the science and presents conclusions regarding the hazard identification analysis that accord with its framework and criteria, and are based on expert judgment with the support of the available scientific evidence.” However, while the conclusion is unchanged, the assessment has been revised to add clarity and transparency regarding the factors most influential to the evidence synthesis and integration decisions for LHP cancers, including myeloid leukemia (see Section 3.3.3).

- Public Comment (ToxStrategies): “In support of leukemia and genotoxicity, the U.S. EPA acknowledges the lack of systemic delivery but then invokes non-specific local mechanisms causing systemic genotoxicity. These views are in direct contrast to other organizations. For example, the OECD test guideline 474 for in vivo micronucleus induction requires proof of systemic delivery of a test article when negative genotoxicity results are to be accepted for regulatory purposes. This implies that the genotoxicity experts who designed the test guidelines anticipate that genotoxicity in distal tissues requires systemic delivery of the test article. The doses in these guideline studies typically include a maximal tolerated dose that would presumably elicit local effects that would, if capable of inducing systemic genotoxicity, interfere with the interpretation of the test results. Since indirect genotoxicity mechanisms are not accounted for in guideline tests, it can be surmised that genotoxicity experts do not consider local effects a capable or meaningful contributor to systemic genotoxicity. Additionally, the purpose of genotoxicity testing guidelines and [a]s acknowledged by the NRC and U.S. EPA, inhaled formaldehyde is not systemically distributed up to 15 ppm. As such, the likelihood that local effects are inducing systemic genotoxicity is low. Data from ADH5 null mice (see above) indicate that even 2-fold increases in serum formaldehyde levels do not cause genotoxicity. Given EPA’s hypothesis that elevated formaldehyde at the portal of entry might cause inflammation or oxidative stress, one might assume that ADH5 null mice, having elevated formaldehyde in all tissues, would have higher levels of oxidative stress and DNA damage, yet this does not appear to be the case.”
  “Table 35 also lists as indirect support for genotoxicity ‘strong and consistent evidence of mutagenicity (increased incidence of MN, CA, and chromosomal aneuploidies) in PBLs of human workers’. Elsewhere in the assessment, U.S. EPA acknowledges that inhaled formaldehyde does not distribute beyond the site of contact. As such, U.S. EPA must believe that these data indicate that there is strong and consistent evidence that low levels of inhaled formaldehyde are potent enough to induce systemic genetic damage through indirect mechanisms. Given that many scientists might find this difficult to believe, it is incumbent on the U.S. EPA to strengthen their position…However, U.S. EPA does little to bolster their conclusions. For example, there is no attempt to evaluate their conclusions vis-à-vis the controlled studies by Speit et al. (2007) and Zeller et al. (2011). U.S. EPA could bolster their conclusions by identifying other chemicals with strong experimental data demonstrating that inhalation exposure results in systemic genotoxicity without systemic delivery of the parent compound or metabolites; however, no such discussion was found…”
  “In a subsection of 1.2.5 on page 1-303 it is stated that “long-term occupational exposure was associated with significantly increased MN in PBLs, and aneugenicity appears to be the predominant effect in peripheral tissues (see Section 1.3.3).” There are three problems in this one sentence. First, the U.S. EPA is referring to information supporting URT carcinogenicity that has not yet been discussed. This makes following their arguments unnecessarily difficult. Second, why would formaldehyde genotoxicity be associated with long-term exposure but not shorter-term exposure? Formaldehyde does not bioaccumulate and data indicate that formaldehyde-related adducts are labile. Similarly, if the damage were due to oxidative stress or inflammation, these too are transient effects that likely resolve. Skipping ahead to Section 1.3.3 I found no explanation; moreover, if there is an explanation in the document it should be recapitulated whenever such data are used to support MOA. The third issue with the above quote is that U.S. EPA states that aneugenicity appears to be the predominant form of genotoxicity in peripheral blood lymphocytes. Considering that aneugenicity is broadly regarded as a threshold form of genotoxicity, it is curious why low-dose linear extrapolation was conducted. Again, I skipped ahead to Section 1.3.3 but found no discussion on the implications of aneugenicity for low dose extrapolation. However, on page 1-524 U.S. EPA concludes that formaldehyde cause aneuploidy in PBLs and clastogenicity in nasal tissues. Notably, Speit et al. (2011) reported that formaldehyde induced clastogenicity but not aneugenicity in cultured cells. Taken together, the reported associations between formaldehyde inhalation exposure and aneugenicity in worker PBLs suggests that such observations are due to something other than formaldehyde exposure.”
- Public Comment (Cardno ChemRisk [now Stantec]): “The EPA largely disregarded the Mundt et al. (2017) fuller analysis of the Zhang et al. (2010) data…Mundt et al. (2017) requested the exposure data via an NCI Technology Transfer Agreement and was provided the average of the three exposure measures for each exposed worker, but not the individual measurements. Thus, the true range of exposure measurements could not be determined. However, they were able to evaluate the relationship, if any, between the average of the individual formaldehyde exposure measurements and all blood and genetic aneuploidy results (Mundt et al. 2017). These results demonstrated no correlation between formaldehyde exposure level (reportedly over at least a fourfold range) and any of the blood or aneuploidy results. Furthermore, the few assay results generated by tests that met the study protocol (e.g., numbers of cells counted, as pointed out by Gentry et al. (2013) appeared to be related to smoking (but not formaldehyde).”
  “Overall, the 2022 Draft does not fully consider or integrate the findings of the fuller analyses that call into question Zhang et al. (2010)’s findings nor does it appropriately integrate evidence from cohort studies reporting ML (and specifically AML) results. The fact remains that there are no studies supporting a MOA for formaldehyde causing leukemias (including AML) and there are several key findings that detract from this hypothesis, e.g., 1) formaldehyde does not form either DNA: protein crosslinks or DNA adducts in bone marrow, 2) exogeneous formaldehyde does not escape the portal of entry, 3) there remains no consistent statistically significant relationships between formaldehyde exposure and chromosome aberrations, sister chromatid exchanges or micronucleated cells in hematopoietic stem cells as conducted in animals, 4) studies in humans exposed to formaldehyde have failed to find a relationship between exposures and chromosomal changes in peripheral blood lymphocytes and 5) the available epidemiological evidence is consistent with no significant increase in LHM, specifically AML, among formaldehyde-exposed workers.”
  “The EPA 2022 Draft Report continues to rely on a cross-sectional study to support a possible MOA for an association between inhalation exposure to formaldehyde and LHMs, based on what they claim (even in the title of the paper) to be “leukemia-specific chromosome changes in cultured myeloid progenitor cells” (Zhang et al. 2010). Cross-sectional studies are incapable of demonstrating changes in clinical markers but might reflect underlying differences between compared groups.”
  “Additionally, the 2022 Draft does not integrate the fuller analyses of the Zhang et al. (2010) data with results of other studies reporting no exposure-dependent differences in blood parameters and genetic markers of formaldehyde-exposed relative to unexposed workers and other cytogenic studies (Casanova-Schmitz et al. 1984; Heck & Casanova, 2004; Lu et al. 2010)or studies examining chromosomal changes in peripheral blood lymphocytes (Bauchinger & Schmid, 1985; Cheotarev et al., 1986; Pala et al., 2008; Suruda et al., 1993; Thomson et al., 1984; Ying et al., 1999) or cytogenetic studies which show genotoxic effects, but fail to show effects on hematopoietic stem cells (He et al., 1998; Shaham et al., 2002; Yager et al., 1986; Ye et al., 2005). These studies largely align with the results of Mundt et al. (2017) and challenge the interpretation that exposure to formaldehyde may induce chromosome or genotoxic changes in blood or chromosomes.” [Please see docket for details and supporting information.]
- Public Comment (University of North Carolina at Chapel Hill): “The IRIS Draft failed to provide adequate evidence to support proposed mechanisms for leukemia, given the fact that inhaled formaldehyde is not systemically distributed at concentrations ≤15 ppm…The study [Lu, Collins, et al. 2010b] demonstrated that exogenous formaldehyde resulted in DNA adducts in rat respiratory nasal mucosa, but did not form [13CD2]-adducts in distant organs remote to the portal of entry. Therefore, the finding provides strong evidence to support a genotoxic and/or cytotoxic MOA for the carcinogenesis of inhaled formaldehyde in respiratory nasal epithelium, but provides evidence against the biological plausibility of inhaled formaldehyde causing leukemia or other systemic effects…The EPA IRIS Draft mentioned several possible mechanisms leading to leukemia from formaldehyde exposure, such as ‘Formaldehyde-induced DNA damage to peripheral blood leukocytes’, ‘formaldehyde-induced systemic oxidative stress’, ‘formaldehyde-induced changes in the bone marrow niche’, etc. However, these hypothesized mechanistic events are not supported or severely confounded by other factors.”
  “Recommendation: The EPA IRIS Draft should provide direct evidence, rather than hypothesis in identifying the mechanisms responsible for leukemia. Further animal exposure studies are warranted to examined whether EPA hypothesized mechanistic events are supported by data, or not, before integration into a weight-of-evidence determination.”
  “The IRIS Draft did not demonstrate adequate understanding of the chemistry underlying formaldehyde reactions with DNA and protein…The EPA IRIS Draft recognized the formation of protein adducts by stating that ‘Formaldehyde can interact with macromolecules…or protein adducts, such as N6-formyllysine.’ or ‘Formaldehyde has been shown to bind to histones and chromatin forming N6-formyllysine’. This may exemplify that the EPA IRIS Draft had no adequate understanding of chemistry underlying formaldehyde reactions with DNA and protein. N6-Formyllysine is by no means a major and highly relevant protein adduct induced by formaldehyde. I and others have demonstrated that Schiff base on lysine residue is the predominant protein adduct induced by formaldehyde…Protein binding has significant impact on the formation of DNA adducts induced by exogenous formaldehyde exposure. For example, we have demonstrated that protein binding can determine the available amount of exogenous formaldehyde to target DNA to form DNA adducts…The EPA IRIS Draft did not provide any perspective on how protein binding would affect the fate of exogenous formaldehyde across tissue space… as my colleagues and I have demonstrated that inhaled formaldehyde at low doses (300 ppb and below) does not induce exogenous DNA adducts even in nasal epithelium. Then, how could exogenous formaldehyde further traverse the epithelium and enter deeper components of the tissues, such as NALT, to induce leukemia?” “Recommendation: EPA needs to revise the IRIS Draft to develop more thorough understanding of chemistry underlying formaldehyde reactions with DNA and protein and how formaldehyde-specific chemistry, such as protein binding, may affect the fate of formaldehyde across tissue space to better support evidence-based formaldehyde risk assessment. Further experiments would be warranted to examine protein binding across tissue space.”
  “The IRIS Draft misinterpreted the findings of our critical, highly human exposure relevant low dose 28-day study, that precludes a mutagenic MOA at concentrations </=0.3 ppm…The EPA IRIS Draft commented that ‘However, in a more recent study with a lower detection limit for adducts and testing lower formaldehyde exposure levels, Leng et al. (2019) did not observe an increase in exogenous hmDNA adducts or DPXs, including in nasal and respiratory tissues as well as at systemic sites (e.g., bone marrow), at formaldehyde levels of 0, 1, 30, or 300 ppb (up to 0.37 mg/m3) after exposure for 28 days.’ Certainly, there is a difference between ‘not observe an increase’ in the EPA IRIS Draft and ‘exogenous adducts were not detectable’ as my colleagues and I reported…I appreciate that the EPA IRIS Draft acknowledged that our low dose study is helpful in improving understanding of DPX formation by stating ‘The lack of detectable exogenous adducts in the URT at 0.3 ppm (0.37 mg/m3) helps to inform the evolving understanding of formaldehyde-induced DPX at lower concentrations, which would benefit from additional study.’ However, EPA IRIS Draft did not explain what additional study would be needed…The EPA IRIS Draft failed to provide reasonable explanations or discuss why no exogenous formaldehyde induced DNA adduct or DPC was detected at low doses.” “Recommendation: Considerably more weight-of-evidence should be assigned to our critical, low dose study. The absence of exogenous DNA adducts/DPC in any tissue, against a background of endogenous formaldehyde over 3,000x higher than the detection limit, should be interpreted in the context of interactions between formaldehyde and protein/DNA, formaldehyde carcinogenicity and the potential for genotoxicity in the absence of DNA exposure. Further clarification on ‘additional study’ is warranted.”
  “The IRIS Draft showed misunderstanding of formaldehyde-induced DNA-protein crosslinks and its role in formaldehyde carcinogenicity…The EPA IRIS Draft stated that ‘While some DPXs may undergo hydrolysis to form N2-hmdG adducts following exogenous formaldehyde exposure, other DPXs appear to be quite stable in vivo; it may be these latter DPXs that play a more important role in formaldehyde-mediated respiratory tract mutagenicity and carcinogenicity.’ However, there is no data to support that Cys-CH2-dG is more important than Lys-CH2-dG in formaldehyde mutagenicity and carcinogenicity…Likewise, the EPA IRIS Draft states that ‘the inability to detect 13C, d2-N6-hmdA was surprising, since 13C, d2-N2-hmdG is reliably quantifiable following low levels of exposure, and increases in an exposure-dependent manner in both rodents, and nonhuman primates (Yu et al., 2015b; Swenberg et al., 2013); the reason for the apparent absence of 13C, d2-N6-hmdA adducts formed by reaction with exogenous formaldehyde remains unknown.’ Statements like this again may reflect the lack of adequate understanding of the chemistry underlying formaldehyde reactions with DNA and protein.” Recommendation: EPA develops adequate understanding of the formation and fate of formaldehyde-induced DPC and revises the IRIS Draft to address the inaccuracy or mischaracterization in the current EPA IRIS Draft.”
  [Please see docket for details and supporting information.]
- Public Comment (Ramboll): “We recently reviewed the US Environmental Protection Agency (USEPA) draft evaluation of noncancer endpoints in the Draft document “Toxicological Review of Formaldehyde―Inhalation” and were dismayed to find that two of our recent papers were not considered in your assessment.
  The first paper, “Do chromosome changes in blood cells implicate formaldehyde as a leukemogen?” addresses an important topic with respect to the USEPA conclusion that formaldehyde can cause myeloid leukemia. It is a comprehensive review of genotoxicity studies of formaldehyde, seeking in vivo evidence in support of the biological plausibility of formaldehyde’s role in the induction of leukemia. In this review, we conclude that although chromosome-level genetic effects, as manifest as chromosomal aberration, or micronuclei formation, in peripheral blood lymphocytes, may be positively associated with the subsequent development of cancer, even when these effects are induced in non-target tissues such as peripheral blood lymphocytes (PBLs). There is no implication of causation in these association studies. The association may simply be due to host susceptibility to developing chromosome aberrations, even those that occur spontaneously. This is consistent with mechanisms of cancer development, in which chromosomal-level mutational changes are important key events in cancer induction. Note, these chromosome-level mutational events in PBLs are independent markers of cancer risk, and not the cause of the subsequent cancer - which occur in the target organ (e.g. the bone marrow niche). Elevated frequencies of chromosomal aberrations or micronuclei in PBLs of workers exposed to formaldehyde therefore do not implicate formaldehyde as a leukemogen, and the use of these studies to suggest that they do is a misinterpretation of those studies.
  The second paper, “Mutagenicity monitoring in humans: global versus specific origin of mutations,” is more indirectly relevant to the USEPA draft report, but nevertheless important. It addresses what in vivo mutation monitoring tells us about the target organ of origin. Assays examining genotoxicity in circulating PBLs in adults do not necessarily reflect a bone marrow origin, and in all likelihood reflect changes occurring in the periphery e.g. circulating blood or peripheral tissues. In newborns and young infants or in rare cases of hematopoietic disorders where the genetic change originated in the bone marrow, the frequency of such alterations in the circulating blood cells would be expected to be 100-fold or more over background, as seen in the few unusual cases discussed in our paper. This second paper extensively reviews the kinetics of blood cells, and illustrates why chromosome changes measured in PBLs in adults do not implicate the bone marrow in their genesis in normal adults. To equate chromosome mutations in rodents with those in humans is to conclude that the mechanism that induces leukemia in the former are also present in the latter. This conclusion is faulty because rodent experimental studies typically measure the aberrations in bone marrow while human observational studies do so in PBLs. By ignoring this critical difference, the EPA fails to recognize that current technology allows routine measurement of bone marrow chromosome mutations in humans by using the reticulocyte micronucleus assays. Results of such studies would allow a critical evaluation of the ability of formaldehyde to induce chromosome mutations in bone marrow cells - something that should be a requisite before concluding that it does.”
  “Although the Zhang et al. (2010a) study has been widely interpreted to suggest the in vivo origins of aneuploidy or initiating genomic instability, the protocol used in this study as well as the underlying data do not support this interpretation. Instead, the data supports aneuploidy arising during in vitro expansion.”
  “While this publication [McGregor et al. 2006] was included, a similar publication on which I am the primary author (Gentry et al. 2020; reference provided below), was not included. The Gentry et al. (2020) publication also applied the IPCS human framework for the analysis of the MOAS that have been postulated for the development of leukemia following formaldehyde inhalation. The integration of the available science for formaldehyde in this publication not only demonstrated the limited amount of data that support any hypothesized MOAS, it also demonstrated the significant amount of research supporting the null hypothesis that there is no causal association between formaldehyde inhalation exposure and leukemia. Further, these analyses increase confidence in the conclusion that there is a lack of biological plausibility for a causal association between formaldehyde inhalation exposure and leukemia… Based on the inclusion of the McGregor et al. (2006) study, I would have expected the consideration of the results of the Gentry et al. (2020) study in the current Draft IRIS Assessment. The science presented in this publication is critical in the determination of the lack of biological plausibility of a causal association between inhalation of formaldehyde and myeloid leukemia and should be considered in finalizing the Toxicological Review of Formaldehyde.”

EPA Response (to the four public comments above): The publications noted above are both review articles, not primary data papers. EPA conducted an independent analysis of the available primary data evidence on formaldehyde and the conclusions drawn may or may not agree with those of the study authors or other review authors. Review articles are tracked as supplemental material and are not necessarily cited in the assessment. For the specific example raised by the commenter, the review by McGregor et al. (2006) is cited in the IRIS assessment three times to summarize information on glutaraldehyde, a URT irritant that doesn’t appear to cause nasal tumors in rats, for comparison to formaldehyde, which does cause such tumors. It is not cited as any type of framework for the MOA analysis. The review by Gentry et al. (2020) does not introduce new evidence informative to EPA’s independent evaluation of MOA. EPA’s conclusions on the primary evidence pertinent to LHP cancer MOA were extensively discussed (Section 3.3.3) and supported by the NASEM panel. Two points of note are provided. One is that knowledge of MOA is not a pre-requisite for identifying a hazard in EPA guidelines or the IRIS Handbook. The second is that the EPA’s cancer guidelines (2005) indicate that when a MOA is unknown, a low-dose linear extrapolation is to be applied. Importantly, however, a quantitative estimate for myeloid leukemia risk is not included in the IUR in the revised assessment, due to too much uncertainty in the underlying data. Accordingly, comments about low-dose extrapolation on LHP cancer risk are viewed as potential future considerations.

### F.4.2 Dose-Response Analysis of Cancer Effects of Formaldehyde

[Please note that for this section, public comments are collated at the end of the section rather than for each subtopic (as was the organization for prior sections)].

#### Charge Question 7. Inhalation Unit Risk (IUR) for Cancer

[Please also see Section “EPA’s use of Toxicokinetic Data and Dosimetry Models” above for additional comments relevant to cancer dose-response modeling using toxicokinetic and dosimetric approaches.]

An IUR for cancer is derived on the basis of nasal cancers using data on nasopharyngeal cancers (NPCs) in a human study from the National Cancer Institute (NCI), specifically the results reported in (Beane Freeman et al., 2013). In addition, comparative estimates are provided on the basis of modeling of nasal tumors in exposed rodents. Finally, although not included in the draft IUR, an estimate for myeloid leukemia is presented. Please comment on the clarity and scientific justification for each specific decision in the draft cancer dose-response analyses outlined in (a) to (d), below, including study selection; POD estimates; and confidence in the calculated values. Part (e) includes a specific, additional question on myeloid leukemia.

a. The NCI study results on NPCs were ultimately selected and used to develop the draft IUR estimate. A lifetable analysis was used to develop a POD and, given the mutagenic MOA for this cancer type, a linear extrapolation was applied. Age-dependent adjustment factors (ADAFs) were applied to this estimate, in accordance with EPA guidelines when a mutagenic MOA is supported. Confidence in the IUR is medium.
b. As a comparison for the modeling of the human data, data from two chronic rat bioassays were used to develop an estimate of nasal cancer risk. Multiple models, including a biologically-based dose-response model, were evaluated and used to extrapolate the results in rats to a POD in humans. A linear extrapolation was applied based on a mutagenic MOA for formaldehyde. Furthermore, a candidate RfC based on cell proliferation was also developed for comparison.
c. For sinonasal cancer, the draft draws an evidence integration judgment of evidence demonstrates. Given the lack of quantifiable data to allow the use of dose-response information to identify a POD, the IUR does not incorporate potential contributions to risk for sinonasal cancer. Please comment on this decision and, if this is not supported, include a recommended method to account for this cancer risk.
d. For myeloid leukemia, a unit risk estimate is presented using the NCI study results (Beane Freeman et al., 2009). The derivation of a unit risk estimate for myeloid leukemia from these data is not straightforward, and several quantitative risk assessment approaches were considered. The selected data set used to derive the myeloid leukemia unit risk estimate combined the results from myeloid leukemia with results for other/unspecified leukemias based on other NCI studies showing that one third to one half of other/unspecified leukemias on death certificates were diagnosed as myeloid leukemias in the hospital. ADAFs were not applied to this estimate, as the assessment concludes that the MOA is unknown.
e. Although the draft concludes that the evidence demonstrates that formaldehyde inhalation causes myeloid leukemia, the only data available to develop a unit risk estimate for myeloid leukemia are uncertain. The draft Toxicological Review discusses the strengths and limitations of the myeloid leukemia estimate in detail. Please comment specifically on how the unit risk estimate for myeloid leukemia should inform the IUR for cancer, if at all.

#### Peer Review Comment Summary

- 0 Tier 1 Recommended Revisions
- 14 Tier 2 Suggested Revisions (Note: one was unnumbered in the NASEM study report)
- 1 Tier 3 Future Consideration
- 34 Consensus Panel Findings (numbered below)

#### General Scope and Approach

##### Peer Review Findings and Comments

- Finding (1): The overall approach and conduct of the cancer dose-response analysis is consistent with EPA’s state-of-practice methods for deriving inhalation unit risk estimates. The 2022 Draft Assessment adequately and transparently evaluates the scientific evidence, and generally documents the dose-response analysis overall in a well-organized and transparent manner. The analyses generally follow the process outlined in the 2022 IRIS Handbook and are consistent with the 2005 Guidelines for Carcinogen Risk Assessment (EPA, 2005a, 2022). As documented in Appendix D and in sections on cancer dose-response analyses, the decision points and analyses are also responsive to the recommendations of the 2011 NRC committee.
- Finding (2): The derivation of unit risk is documented in approximately 200 pages in total across the three documents in the 2022 Draft Assessment—the Assessment Overview, Main Assessment, and Appendices—and some redundancies are evident within and across the documents. The sections documenting the derivations based on epidemiological evidence are transparent, and overall are well written and understandable.

EPA Response to Finding 2: EPA notes that the Assessment Overview has not been retained in the revised assessment (again, noting that this document was not intended as a component of the principle analyses, but rather a distilled summary overview of the Toxicological Review and Appendices).

#### Inhalation Unit Risk for Nasopharyngeal Cancer from Epidemiological Data

##### Study Selection

###### Peer Review Findings and Comments

- Finding (3): EPA’s selection of the Beane Freeman et al. (2013) occupational retrospective mortality study is appropriate and is consistent with the earlier recommendation of the 2011 NRC committee (NRC, 2011, p. 88) that EPA should update the unit risk value when this study became available. While the selection of this study is appropriate, and the major factors for its selection are described, the narrative discussion lacks clarity. The 2011 NRC committee called for EPA to “develop, state, and systematically apply a set of selection criteria for studies and cancer end points” (NRC, 2011, p. 145).
- Tier 2 Suggested Revision (Recommendation 5.4): While the criteria for selecting the Beane Freeman et al. (2013) study can reasonably be discerned from the 2022 Draft Assessment, EPA should provide clearer statements of the criteria and comparison of studies with such criteria, in tabular format, to improve transparency and clarity. EPA should add to such a table other studies that evaluated the same cancer outcome so it is apparent why the selected study was superior for the purposes of dose-response analysis.

EPA Response to Tier 2 Suggested Revision 5.4: EPA has added considerations for selecting studies to advance to dose-response analysis (i.e., are they more/most appropriate for use in estimating a POD) to the assessment methods (Section 2.7 in the revised Toxicological Review); these general considerations are applicable to both cancer and noncancer health effects. Note that decisions on which studies are advanced involves pros and cons of the available evidence rather than strict criteria. A table documenting the application of the considerations to the available studies was added for each quantified cancer type in Section 5.2 of the revised assessment to clarify the justification for study selection in deriving cancer toxicity values.

##### Endpoint Selection

###### Peer Review Findings and Comments

- Finding (4): The selection of nasopharyngeal cancer mortality is appropriate given its causal link to formaldehyde exposure in humans. Nasopharyngeal cancer incidence would be the preferred endpoint over mortality, but could not be modeled because of the study design (mortality cohort). The decision not to develop a unit risk for the sinonasal cancer outcome can be justified on the basis of the small number of cases and the quality of the dose-response relationship in the study.

##### Dose Metric Selection

###### Peer Review Findings and Comments

- Finding (5): The selection of cumulative exposure as the dose metric is adequately justified. The use of cumulative exposure as the dose metric in dose-response modeling is consistent with the 2022 IRIS Handbook (EPA, 2022 p. 8-4): “Cumulative exposure (or a dose metric that can be converted to cumulative exposure) is generally the preferred exposure metric for cancer responses; exposure estimates can include a lag period, if warranted.” EPA’s language in Guidelines for Carcinogen Risk Assessment (EPA, 2005a, p. 3-26) is less definitive with regard to preferential use of the cumulative exposure metric: “Unless there is evidence to the contrary in a particular case, the cumulative dose received over a lifetime, expressed as average daily exposure prorated over a lifetime, is recommended as an appropriate measure of exposure to a carcinogen… This approach becomes more problematical as the exposures in question become more intense but less frequent, especially when there is evidence that the agent has shown dose-rate effects” (EPA, 1986a).
  ○ Additional committee comments relevant to Finding 5: “Although EPA stated that the peak exposure metric produced the strongest exposure-response relationships, it did not use this metric because it is not based on exposure concentration measurements. In addition, EPA expressed uncertainty about how to use peak exposure-based estimates in predicting risks for lifetime exposure to continuous low exposures. Because the average exposure metric did not account for duration and duration does not account for level of exposure, these metrics also were not used.”

##### Model Selection and Fit

###### Peer Review Findings and Comments

- Finding (6): EPA followed a process consistent with its state-of-practice methods in conducting the dose-response analysis on nasopharyngeal cancers. Log-linear Poisson regression is a standard, widely used, and acceptable approach for modeling large occupational data sets such as that reported in Beane Freeman et al. (2013) (25,610 workers; 998,239 person-years of follow-up). The selected lag period of 15 years was based on expert judgment with supporting evidence; the committee finds this to be appropriate for modeling solid tumors.
- Finding (7): There is uncertainty about the degree to which peak exposure produces the strongest exposure-response relationships. Inclusion of the zero-response group shows a slightly less significant trend for peak exposure (p = 0.1 for trend) compared with the use of cumulative exposure as a metric (p = 0.07).
- Tier 2 Suggested Revision (Recommendation 5.5): EPA should acknowledge the uncertainty involved in interpreting the analyses on the degree to which exposure-response relationships are stronger than cumulative exposure for determination of peak exposure and risk.

EPA Response to Tier 2 Suggested Revision 5.5: The assessment has been revised to acknowledge uncertainty that peak exposure produces the strongest exposure-response relationships (see Section 5.2).

##### Point of Departure and Inhalation Unit Risk for Nasopharyngeal Cancer Mortality

###### Peer Review Findings and Comments

- Finding (8): In evaluating the nasopharyngeal cancer outcome, EPA’s approach of using a life-table procedure to account for competing causes of death in applying the regression coefficient to estimate extra-risk levels is a standard approach for dose-response assessments that are based on epidemiological evidence.
- Finding (9): EPA’s choice of an extra-risk value of 0.05 percent for the POD is consistent with its Guidelines for Carcinogen Risk Assessment (EPA, 2005a, p. 3-16): “The POD is an estimated dose (expressed in human-equivalent terms) near the lower end of the observed range without significant extrapolation to lower doses.” Because elevated relative risks in the Beane Freeman et al. (2013) study were associated with significant findings in the range of 2.94 to 11.54, the POD of 0.11 ppm, which is associated with a relative risk of 3.6, can be considered as being at the lower end of the observed range.
- Finding (10): EPA’s calculation of the unit risk for mortality is appropriate and consistent with its Guidelines for Carcinogen Risk Assessment (EPA, 2005a, p. 3-23).
- Finding (11): Insufficient information is given on the details of the dose-response analysis and the derivation of the unit risk values. For example, the 2022 Draft Assessment states, “An adjustment was also made for the 15-year lag period” (p. 2-50), without explaining how the adjustment was made. In addition, Appendix B, Table B-18 shows no exposure in infancy and childhood in the life-table example for the derivation of a unit risk for environmental exposures.
- Tier 2 Suggested Revision (Recommendation 5.6): EPA should state how the adjustment for the 15-year lag was made for nasopharyngeal cancer mortality, and explain the assignment of zero exposure in Table B-18.

EPA Response to Tier 2 Suggested Revision 5.6: The assessment text was revised to clarify how the adjustment for a 15-year exposure lag was made for NPC mortality and explain the zero exposures (see Appendix D.2.1 of the revised assessment).

##### Inhalation Unit Risk for Nasopharyngeal Cancer Incidence

###### Peer Review Findings and Comments

- Finding (12): EPA’s derivation of the unit risk estimate for formaldehyde-associated nasopharyngeal cancer incidence was appropriately done, and the preference for that estimate over the mortality-based unit risk estimate is appropriate and consistent with the 2022 IRIS Handbook (EPA, 2022, p. 8-4) and EPA’s Guidelines for Carcinogen Risk Assessment (EPA, 2022, p. 3-12).
- Finding (13): The prediction of the number of annual incident cases in the U.S. at upper ends of outdoor (5 ppb) and indoor (20 ppb) formaldehyde exposure levels as a “reality check” on the inhalation unit risk is a useful exercise that would be improved by acknowledging some of the possible environmental and other causative factors of nasopharyngeal cancer in the United States.

EPA Response: Factors that might contribute to NPC risk were evaluated for consideration during evaluation of potential confounding within individual health effect studies. However, as IRIS assessments do not include exposure assessment and perspective on risk due to different exposure scenarios are the purview of subsequent EPA (or other) risk assessments, the recommended discussion was not added in the revised IRIS assessment.

- Tier 2 Suggested Revision (Recommendation 5.7): In Appendix B, Table B-12, increasing the number of significant figures in columns P, H, and L to align with column I would add transparency by making it easier for readers to follow and understand the calculations for nasopharyngeal cancer incidence.

EPA Response to Tier 2 Suggested Revision 5.7: EPA has added significant figures to the table entries where such details were available.

#### Inhalation Unit Risk for Nasal Cancer from Animal Bioassay Data

##### Study Selection

###### Peer Review Findings and Comments

- Finding (14): EPA’s selection of studies was appropriate. The studies were identified as having high confidence (Section 1.2.5), and each used large numbers of animals per dose group. However, Table 1-37 (p. 1-296) in Section 1.2.5 lays out five high-confidence studies with dose-response data. The reason for not selecting the three other high-quality studies is not discussed or referenced in the dose-response section “Animal Nasal Tumor Incidence.”

EPA Response to Finding 14: EPA has added text to Section 5.2.1 that discusses issues with the studies on rats by Woutersen et al. (1989); Sellakumar et al. (1985); Kamata et al. (1997);Holmstrom et al. (1989b) and the merits of the (Kerns et al., 1983) and (Monticello et al., 1996) studies for conducting dose-response analyses. The section also indicates why the studies on mice were not suited for dose-response.

- Finding (15): Combining similarly designed studies is an acceptable approach when data harmonization is feasible. While EPA notes that “the incidences are similar in the two studies,” it does not fully discuss the homogeneity or heterogeneity of the two studies and did not adopt statistical approaches to address study heterogeneity. Further, EPA does not clearly state that the data relied upon in the analysis are documented in a memorandum by Elizabeth Gross Bermudez from the Chemical Industry Institute of Toxicology (CIIT) correcting the incidence data and dose levels used in the two studies. Both studies were conducted by CIIT. Kerns and colleagues (1983) report that they used the concentrations 0, 2.0, 5.6, or 14.3 ppm with 6 hours per day and 5 days per week exposure for up to 24-months, followed by a nonexposure period of 6 months and with interim sacrifices at 6, 12, 18, 24, 27, and 30 months. Monticello and colleagues (1996) report that they used concentrations of 0, 0.7, 2.0, 6.0, 10, or 15 ppm with 6 hours per day and 5 days per week exposure for up to 24 months and interim sacrifices at 3, 6, 12, 18, and 24 months. EPA reports concentration levels of 0, 0.7, 2.0, 6.01, 9.93, or 14.96 ppm for the two studies combined, as provided in the Bermudez memorandum and in Table 2-20 of the 2022 Draft Assessment. Listing Bermudez as one of the references for the animal incidence data in Table 2-20 on p. 2-54 without further explanation is insufficient and confusing.
- Tier 2 Suggested Revision (Recommendation 5.8): EPA should describe more clearly the procedure and justification for pooling the data from two animal studies into one analysis, and clarify that combined and corrected incidence data are contained in the Bermudez memorandum, which is not readily accessible to the public. The individual animal data for time-to-tumor occurrence used in the model should be provided in an appendix.

EPA Response to Tier 2 Suggested Revision 5.8: EPA has added text related to the F344 rat nasal cancer incidence data that addresses the following (with supporting analyses) in Appendix D.2.2 of the revised assessment:

- Dose-response data pooled from the (Monticello et al., 1996; Kerns et al., 1983) studies were found to be statistically homogenous, and supporting combining the two studies for increased power in the dose-response analysis.
- In 2004, CIIT issued a memo to EPA that corrected errors in the original report for the (Kerns et al., 1983) study; the memo (Bermudez, 2004) is reproduced in the Appendix in its entirety.
- The individual animal data obtained from CIIT are reproduced.

- Finding (16): Another advantage of the two CIIT studies is that they provide time-dependent SCC incidence data, and also have companion mechanistic investigations pertaining to the nasal carcinogenicity of formaldehyde. The mechanistic data generated for the CIIT studies include site-specific DNA–protein crosslinks (DPC) as a marker of tissue dose, as well as site-specific changes in cell labeling as a measure of cell division rate.

##### Cancer Endpoint Selection

###### Peer Review Findings and Comments

- Finding (17): EPA’s selection of SCC as the cancer endpoint is appropriate and consistent with its state-of-practice methods.

##### Dose-Response Modeling

###### Peer Review Findings and Comments

- Finding (18): EPA’s reanalysis largely reproduced the results of Conolly et al. (2003) (Figure 2-4). EPA conducted a thorough uncertainty analysis of the BBDR model, investigating the structure of the model, uncertainties of the model parameters, and model sensitivities to these parameters (Appendix B, Section B.2.2). EPA provides an in-depth discussion of uncertainties from four sources that have potentially larger impact: PBPK model for DPC, use of historical controls, cell replication rates from the labeling data, and model specification for initiated cell kinetics.
- Finding (19): Together, these modeling efforts were highly responsive to the recommendations of the 2011 NRC committee regarding the use of CFD and BBDR models and modeling of time-to-tumor and time-to-death data.
- Finding (20): EPA does not present details of model specification or results of the MSW model and the Weibull incidence model in either the Main Assessment or Appendix B. The form of the Weibull model is not presented. The use of these models came with many restrictions on the parameters that affected the model-fitting results. Regarding the MSW model, it is unclear how EPA treated the lapsed-time parameter t0—a crucial parameter—although EPA does describe the approach to coding animals with lethal versus incidental tumors. It is also unclear why EPA set the first 5 coefficients to 0 and estimated only the coefficient for the term of fifth power in the multistage polynomial. Although the reader is referred to Appendix B, Section B.2.2 for details, the information on MSW modeling could not be located. The relationships between the administered concentration and the DPC and flux metrics for the rat and the human are not provided. Dose-response fits for the MSW for administered concentration using time-to-tumor data would be informative and useful for comparison given the described uncertainties in the estimates of the dose metrics.
- Tier 2 Suggested Revision (Recommendation 5.9): To enhance transparency, EPA should provide additional detail on the modeling, including constraints imposed on model parameters, the results of model fitting (goodness-of-fit test), and the approach used to define lag parameters. The relationship between administered dose and the DNA– protein crosslinks and flux dose metrics should also be provided. Given the uncertainties in the dose surrogates, a dose-response analysis and benchmark concentration calculations using administered concentrations should be provided as a point of comparison.

EPA Response to Tier 2 Suggested Revision 5.9:

- Details regarding the Multistage Weibull time-to-tumor modeling (parameters and model fits) of the (Monticello et al., 1996; Kerns et al., 1983) studies had been accidentally left out of the document submitted for peer-review and EPA thanks the reviewer for pointing this out. A section in Appendix D.2.2 (referenced in Section 5.2.1 of the main text under Time-to-tumor modeling without using mechanistic data) now provides details of the dose-response analyses, estimation of parameters, and plots of model fits for fatal and incidental tumors. The value for the lag parameter t0 was zero. The first 5 coefficients were estimated in the course of the model fit to be zero (they were not fixed at this value).
- A goodness-of-fit test could not be carried out as this is not available in the software, therefore the model fit was assessed by visual comparison against Kaplain-Meir survival estimates.
- A Table providing the flux levels has been added in the revised Appendix.
- A Table providing flux levels against average DPX levels has also been added in the revised Appendix. The DNA protein cross link estimates used for the dose-metric in the (Schlosser et al., 2003) study were generated using a physiologically based pharmacokinetic model that used CFD-model generated values of formaldehyde flux to the tissue as input. This is now clearly stated in the text.
- EPA agrees with the recommendation to provide results based on administered exposure concentration of formaldehyde as the dose-metric. These are now added in Appendix D.2.2.

##### Benchmark Dose Modeling

###### Peer Review Findings and Comments

- Finding (21): The estimates of BMC and BMCL at benchmark response (BMR) levels of 0.01, 0.05, and 0.10 are comparable across the MSW and Weibull (with threshold) models and the BBDR models. EPA also shows (in Table 2-22) that the BMC and BMCL estimates at the BMR = 0.005 level are similar in the two versions of BBDR. Human equivalent concentration (HEC) estimates are also similar. As expected, the Weibull threshold model produced slightly higher estimates. EPA’s exercise showed that, assuming the models fit the data well, the model-related uncertainty is limited.

###### Uncertainty and Variability

- Finding (22): EPA’s discussion of the variability and uncertainty in the BBDR models is extensive. The 2022 Draft Assessment correctly states that the statistical uncertainties outside of the data range for the model can be higher. However, the example provided for the MSW model (p. 2-69, line 7-10) is difficult to follow, in part because the full results of the model are not given. The MSW model is quoted identically twice (p. 2-69, line 7- 10; p. 2-79, line 7-9) for dose-response estimation and low-dose risk without extrapolation, respectively.
- Tier 2 Suggested Revision (Recommendation 5.10): EPA should organize the discussion of uncertainties and variabilities in a manner that is easier to follow, such as by models or by process (models, benchmark concentration estimation, lower dose extrapolation, or extrapolation from animal data to humans).

EPA Response to Tier 2 Suggested Revision 5.10: The uncertainties and variabilities discussion has been revised, as described above. However, given that the uncertainties overlap and are interwoven, the discussion was not re-organized as suggested.

- Tier 2 Suggested Revision (Recommendation 5.11): The results from different models and different databases are remarkably similar, supporting each other and suggesting a good degree of robustness. EPA should highlight this robustness to a greater degree while not losing sight of uncertainties within individual studies, endpoints, and models.

EPA Response to Tier 2 Suggested Revision 5.11: The similarities in the estimates, which increase confidence in the selected estimate, are highlighted and emphasized in the revised draft (Section 5.2.1).

#### Selection of a Unit Risk Estimate for Nasal Cancer

##### Peer Review Findings and Comments

- Finding (23): EPA’s selection of the inhalation unit risk based on human nasopharyngeal cancer is appropriate and acceptable. The committee concurs with EPA’s choice of cumulative exposure as the metric.

#### Uncertainties and Confidence in the Preferred Unit Risk Estimate for Nasal Cancers

##### Peer Review Findings and Comments

- Finding (24): EPA discusses the uncertainties for the human inhalation unit risk estimate after discussing inhalation unit risk estimates for animal SCC data and the selection of a preferred unit risk estimate. With only 10 cases of nasopharyngeal cancer–specific deaths in the NCI cohort, the use of nasopharyngeal cancer for deriving an inhalation unit risk carries uncertainties, although the monotonic trend (in rate ratio based on the Poisson regression model) somewhat strengthens the dose-response trend (p = 0.07). The strength of dose-response between formaldehyde exposure and nasopharyngeal cancer–related deaths can also be affected by other factors, including the confounding of age and misclassification of exposure, which create additional and important uncertainties for discussion.
  ○ Additional committee comments related to Finding 24: “…a very rare cancer. This study followed more than 25,000 workers for over 40 years and observed a statistically significant increase in RR associated with the highest category of average exposure intensity, however, only 10 cases occurred. The small number of deaths creates uncertainties for the dose-response modeling (borderline significant trend test for cumulative exposure including exposed and unexposed person-years, p = 0.07).
- Tier 2 Suggested Revision (Recommendation 5.12): EPA should discuss the extent to which the inhalation unit risk estimates based on animal squamous cell carcinoma data and mechanistic data provide supporting evidence for the inhalation unit risk based on the human nasopharyngeal carcinoma data.

EPA Response to Tier 2 Suggested Revision 5.12: Section 5.2.1 (e.g., Table 5-42) shows that the unit risks computed from animal and human data are comparable to a surprising degree, and the text surrounding the Table makes this point.

- Finding (25): EPA mischaracterizes the p-value for trend as a p-value for goodness of fit (e.g., Table 2-28; p. 86, lines 8–9; p. 91, lines 13–14).
- Tier 2 Suggested Revision (Recommendation 5.13): EPA should address technical errors, such as mischaracterization of a trend p-value, with a thorough and technical edit and proofreading.

EPA Response to Tier 2 Suggested Revision 5.13: EPA has addressed these technical errors in the revised assessment.

#### Inhalation Unit Risk for Myeloid Leukemia from Epidemiological Data

##### Study Selection

###### Peer Review Findings and Comments

- Finding (26): The Beane Freeman et al. (2009) study was appropriately selected, and the rationale for its selection over Hauptmann et al. (2009) is adequate.

##### Inhalation Unit Risk Value for Myeloid Leukemia

###### Peer Review Findings and Comments

- Finding (27): EPA’s use of the same general approach for myeloid leukemia as for nasopharyngeal cancer in deriving unit risk estimate was appropriate. The grouping of myeloid leukemia with other/unspecified leukemia to address possible underreporting of myeloid leukemia was a practical approach, but as recognized in the 2022 Draft Assessment, likely created overcounting of myeloid leukemia since half to two-thirds of the other/unspecified category could be nonmyeloid leukemia. Both under- and overreporting of myeloid leukemia can alter the true shape of the dose-response by impacting the cancer deaths across exposure levels and statistical power in an uncertain fashion.
- Finding (28): EPA states that the p-value of 0.44 for trend is indicative of a poor model fit. This conclusion is erroneous, and this error occurs throughout this section (e.g., p. 2-86, line 8-9; p. 2-91, line 14; Table 2-36, last bullet point). Rather, this p-value is indicative of the lack of statistical significance for the association between myeloid leukemia death risk and cumulative formaldehyde exposure, which results largely from the nonmonotonic relative risk trend seen in the reported data (0.82 and 1.02 in the second and third exposure categories, respectively; Table 2-29). In contrast, a monotonic trend is observed under the metric of peak exposure (p = 0.07; Table 2-29).
- Tier 2 Suggested Revision (Recommendation 5.14): EPA should discuss the implications and interpretation of nonmonotonic dose-response relationships observed with the cumulative exposure metric (e.g., p. 2-92, lines 2–4).

EPA Response to Tier 2 Suggested Revision 5.14: The uncertainties in the dose-response assessment of myeloid leukemia are outlined in Section 5.2.2 of the revised assessment, with additional discussion in Appendix D.2.3. The revision makes clear that the unit risks that can be calculated are too uncertain for use in the IUR.

##### Uncertainty in the Myeloid Leukemia Inhalation Unit Risk

###### Peer Review Findings and Comments

- Finding (29): The degree of monotonicity of the dose-response in the data dominates the statistical significance of the exposure-response trend. Therefore, combining other/unspecified leukemia with myeloid leukemia does not necessarily reduce the uncertainty due to underreporting of myeloid leukemia.
- Finding (30): EPA estimated inhalation unit risks for all leukemias, myeloid leukemia and other/unspecified leukemia combined, and myeloid leukemia separately, and concluded that these estimates were similar (Tables, 2-34 and 2-35). In part because of the weak dose-response relationship for cumulative exposure and myeloid leukemia data in the NCI cohort, the likely significant underreporting of myeloid leukemia, and the uncertainty in the optimal exposure metric, EPA determined that the inhalation unit risk estimate for myeloid leukemia is of low confidence. The committee concurs with the decision not to carry the myeloid leukemia risk estimate forward into the overall inhalation unit risk estimate for formaldehyde.
- Tier 2 Suggested Revision (Recommendation 5.15): In the discussion of uncertainties and confidence in the inhalation unit risk for myeloid leukemia, EPA should include the unknown dose rate-response relationship, the choice of statistical model and method, and the lack of understanding of mechanism. The three estimates in Table 2-35 should be presented as alternative, low-confidence inhalation unit risk estimates for myeloid leukemia without selection of a preferred estimate. EPA should not characterize the combining of other/unspecified leukemia with myeloid leukemia as “the best approach.”

EPA Response to Tier 2 Suggested Revision 5.15: The uncertainties in the dose-response assessment of myeloid leukemia are outlined in Section 5.2.2 of the revised assessment, with additional discussion in Appendix D.2.3. The revision classifies the unit risk that can be calculated is too uncertain for use in the IUR. Discussion of a “preferred” unit risk have been removed throughout. EPA has clarified that the unit risk estimate combining other/unspecified leukemia is “the best available approach” rather than “the best approach,” making it clear that while EPA does still consider it to be the best estimate that is currently derived in the assessment (as it leverages the most available information), it remains too uncertain for use in the IUR.

#### Human-Based Unit Risk Estimates for Potential Increased Early-Life Susceptibility

##### Decision to Apply Adjustment for Increased Early-Life Susceptibility

###### Peer Review Findings and Comments

- Finding (31): EPA’s application of ADAFs is consistent with its Supplemental Guidance for Assessing Susceptibility from Early-life Exposure to Carcinogens (EPA, 2005b), which states (p. 36): “ADAFs are only to be used for agents with a mutagenic mode of action for carcinogenesis when chemical-specific data are absent.
  ○ Additional committee comments related to Finding 31: While there is uncertainty in the degree to which nonmutagenic processes may also contribute to the carcinogenic activity of formaldehyde inhalation at the point-of-entry tissues, there is sufficient evidence to support the assumption that a mutagenic MOA is involved in the carcinogenesis of formaldehyde in the upper aerodigestive tract in humans. Furthermore, there are no formaldehyde-specific data to inform adjustments for early-life exposure, which further supports use of the default procedure as discussed in the Supplemental Guidance for Assessing Susceptibility from Early-life Exposure to Carcinogens (EPA, 2005b). Finally, this [EPA’s] approach is concordant with the Guidelines for Carcinogen Risk Assessment (EPA, 2005a) which states (p. 3-22): “If there are multiple modes of action at a single tumor site, one linear and another nonlinear, then both approaches are used to decouple and consider the respective contributions of each mode of action in different dose ranges. For example, an agent can act predominantly through cytotoxicity at high doses and through mutagenicity at lower doses where cytotoxicity does not occur.”

##### Approach to Adjustment

###### Peer Review Findings and Comments

- Finding (32): The use of multiple terms for the same item is confusing, and the “preferred inhalation unit risk” conflicts with the definition of “inhalation unit risk” in EPA’s online IRIS glossary: “Inhalation Unit Risk Definition: The upper-bound excess lifetime cancer risk estimated to result from continuous exposure to an agent at a concentration of 1 μg/m³ in air. The “ADAF-adjusted unit risk estimate” meets this definition, while the “preferred” estimate does not. EPA intends the “preferred” estimate to be used in applications for which ADAFs are used to address less-than-lifetime exposures, particularly early in life, or risks when exposure varies with age.
  ○ Additional committee comments related to Finding 32: “Calculations were then made using this “adult-based” inhalation unit risk and ADAFs to derive a total lifetime inhalation unit risk estimate assuming exposure from birth to 70 years of age. The resulting estimate is termed a “lifetime unit risk estimate” (p. 2-99). The “adult based” unit risk estimate is identified as the “preferred inhalation unit risk estimate,” and the “lifetime unit risk estimate” is termed the “ADAF-adjusted unit risk estimate”. (p. 2-102).”

EPA Response to Finding 32: The revised Toxicological Review no longer uses the term “preferred” in this manner.

- Tier 3 Future Consideration (Recommendation 5.16): Terminology for inhalation unit risk estimates and for potency values used in applying ADAFs should be consistent across the IRIS Program, including with terms in the IRIS glossary.

EPA Response to Tier 3 Future Consideration 5.16: This future consideration encouraging consistency in future assessments is noted.

- Tier 2 Suggested Revision (Recommendation 5.17): For clarity, EPA should include the lifetable calculations for the adult-only unit risk estimate in Appendix B.

EPA Response to Tier 2 Suggested Revision 5.17: An illustration of the lifetable analysis is provided in Appendix D.2.1 of the revised assessment.

#### Confidence in the Unit Risk Estimate

##### Peer Review Findings and Comments

- Finding (33): The sources of uncertainty are well described, and the committee finds the assignment of medium confidence appropriate and consistent with EPA’s state-of-practice methods. The committee agrees that there is substantial uncertainty regarding extrapolation to lower doses, but notes that the degree of extrapolation is less than typical in environmental health risk assessment because the POD was already at the risk level of 0.05 percent excess risk and well within the range of observation. The committee also agrees that the failure to incorporate in the unit risk estimate cancer activity for cancers other than nasopharyngeal that are causally related to formaldehyde exposure (myeloid leukemia and sinonasal cancer) could raise the possibility of a bias toward underestimation of risk.

#### Appropriate Exposure Circumstance

##### Peer Review Findings and Comments

- Finding (34): The dose-response analysis in Section 2 does not explicitly address the meaning of “appropriate exposure circumstances” in the context of the cancer hazard identifications in Section 1, and in fact nowhere in Section 2 is that term found. Consequently, readers are left uninformed as to how EPA is qualifying its cancer hazard conclusions.
- Tier 2 Suggested Revision (Recommendation “5.18”; [Note: revision not numbered in NASEM report]): EPA should clearly articulate what is meant by “appropriate exposure circumstances” in Section 2 or abandon the use of the term.

EPA Response to Tier 2 Suggested Revision 5.18: For consistency with the IRIS Handbook and current approaches, this phrasing was replaced with “sufficient exposure conditions” throughout. In addition, footnotes and explanations have been added to clarify that this phrasing is used to highlight in the hazard identification-specific sections that the dose-response analyses defining the conditions of exposure that might be necessary for the effects to manifest are evaluated in the separate dose-response section (for those health effects with sufficient evidence of a hazard). Specifically, “For each credible hazard identified (in this assessment, judgments of evidence demonstrates or evidence indicates [likely]; see Section 2.6 for details on drawing these judgments), the “sufficient exposure conditions” (e.g., exposure level, duration, timing, frequency) alluded to during hazard identification in Section 3 are more fully evaluated and defined through dose-response analysis in Section 5, including, depending on the evidence available, the derivation of toxicity values.” It is noted that this language is not used in association with the carcinogenicity conclusions; the revised assessment was reviewed to remove any such inferences.

#### Public Comments on Dose-Response Analysis of Cancer Effects of Formaldehyde

- Public Comment (Louisiana Chemical Association): “The inhalation unit risk (IUR) for BPC was developed using the NCI cohort study (Beane Freeman et al., 2013) as “it is the only one with sufficient individual exposure data for dose response modeling” (EPA, 2022a). The weak and inconsistent associations, methodological issues, and external confounders of the study are mentioned above and are discussed in detail in the cited references.
  The IUR for NPC is based on a mutagenic mode of action (MOA) which assumes a linear non-threshold (LNT) dose response (EPA, 2005). The available science does not support the use of a LNT assumption to estimate toxicity criteria for formaldehyde, a chemical which EPA acknowledges has a mixed MOA and evidence of non-linear dose response relationships (EPA, 2022a & b).”
  “EPA applied age-dependent adjustment factors (ADAFs) to develop the UR for NPC which is typically done for chemicals with a mutagenic MOA. However, EPA acknowledges that the carcinogenicity of formaldehyde can be attributed only in part to a mutagenic MOA. The scientific defensibility of applying ADAFs to the toxicity criteria for a chemical known to have a multi-faceted MOA, non-linear dose-response relationships, and an effect threshold is questionable.”
  “The 2022 NPC IUR is 1.1 × 10-5 per μg /m3 (1.1 excess cancer cases are expected to develop per 100,000 people if exposed daily for a lifetime to 1 μg/m3). The overall confidence level of EPA in the NPC IUR is medium based largely on ‘The small number of cases that contributed to the statistical analysis and resulting imprecision in modeling the shape of the dose-response curve’ (EPA, 2022a). The 2022 NPC IUR is similar to the 1991 IUR of 1.3 × 10-5 based on nasal squamous cell carcinomas in F344 rats (EPA, 2022a).” [Please see docket for details and supporting information.]
- Public Comment (American Chemistry Council): “With regard to nasal tumors, there is substantive evidence indicating these tumors are the result of cytotoxicity and regenerative proliferation. In its derivation of IURs based on animal data, EPA presents an analysis of potential threshold-like effects (i.e., an RfC based on cellular proliferation). Ultimately, however, EPA concludes that because the formaldehyde-induced tumors could not solely be attributed to cell proliferation and that the evidence “at least in part” supported a mutagenic MOA, a linear no-threshold approach was supported. However, the existence of multiple MOAs does not preclude EPA from deriving toxicity values based on threshold-like responses. In the case of formaldehyde, if genotoxicity were to occur, it is expected only above those exposures associated with regenerative cell proliferation, as noted by the ECHA RAC Committee (2020) quoted above. Given the robust scientific evidence that the non-genotoxic MOA predominates and would be protective of any other MOA for carcinogenicity, EPA should consider assessing formaldehydye nasal cancer potency using a threshold approach, rather than a linear, no-threshold IUR.”
  “The Draft Assessment concludes that a mutagenic MOA is operative for nasal tumors and, therefore, low dose linear extrapolation is required and fails to integrate data demonstrating that both the tumorigenic response and exposure to the molecular target (i.e., DNA) are highly non-linear.”
  “The draft Formaldehyde Review does not mention the MOA evaluation by Thompson et al. (2020). This analysis of the dose-response indicates there is a threshold for genotoxicity and that it is higher than the threshold for nasal tumors. As such, a threshold approach based on nasal tumors in rats would be protective for any tumors resulting from genotoxicity. The MOA information, together with the robust toxicity database for formaldehyde, provides ample evidence to ‘’justify a conclusion that mutagenicity is not operative at low doses and focus on a non-linear approach,” in accordance with the 2005 Guidelines. In addition to the updated MOA by Thompson et al. (2020), authoritative sources have concluded there is a threshold for both nasal tumors and genotoxicity: i. ECHA Committee for Risk Assessment (RAC). 13 March 2020. Opinion on an Annex XV Dossier Proposing Restrictions on Formaldehyde and Formaldhyde Releasers…ii. WHO. 2010. WHO Guidelines for Indoor Air Quality: Selected Pollutants. World Health Organization, Regional Office for Europe.”
  “Concordance of effects and other information that supports a threshold MOA, supported by dosimetry was excluded from the assessment. Understanding that the nasal tumors form only at exposure levels at which normal homeostasis has been upset is a critical point in apprehending why a threshold is observed in tumor response. These data [Thompson et al. 2020; Andersen et al. 2010] argue strongly against the use of low dose linear extrapolation into the zone of homeostasis (below background levels of endogenously produced formaldehyde).” “EPA’s carcinogenicity risk-assessment guidelines recommend considering alternative models, especially when biologically based dose-response models are unavailable (EPA 2005). That exercise is especially important when a single study with uncertainties associated with selected cancers and inconsistency with exposure metrics is used. Despite this guidance the Draft Assessment concludes that Formaldehyde is a Human Nasal Carcinogen that acts via a genotoxic mechanism, with a linear dose response, and excludes consideration of the cytotoxic and regenerative hyperplasia threshold MOA recently updated by Thompson et al. (2020), as an alternative MOA.”
  “… EPA’s linear unit risk estimate for NPC is essentially unchanged from the value derived over 30 years ago, despite the prodigious growth in the scientific database on formaldehyde indicating that formaldehyde is a threshold carcinogen.”
  “Toxicodynamics and toxicokinetics considerations, demonstrating highly non-linear dosimetry, were not taken into consideration when deriving quantitative estimates of risk.”
  “EPA’s formaldehyde cancer slope factor is not based in reality. It projects that background formaldehyde levels of 5 and 20 ppb will result in 8 and 20% of the annual NPC US incidence in non-smokers, or of 16 and 40% of the population when smokers are included. Moreover, using an EPA cited background NPC incidence of 0.6 per 100,000 folks, EPA’s cancer slope factor for formaldehyde, and average indoor formaldehyde concentrations, projects incidences at 20 or 51% of the annual NPC US incidence rate. These values clearly do not match the available literature, which shows minimal, if any, background NPC due to formaldehyde, nor is it consistent with highly reliable biomarker of exposure/molecular dosimetry data that indicates little to any exogenous formaldehyde entering cells at average indoor air concentrations, against a high background of endogenous exposure of the DNA. The molecular dosimetry data demonstrates that inhalation exposures could not have added risk of more than 1/3,000th of the endogenous risk. With an average incidence rate of ~2,000 per year in the US, based molecular dosimetry, at maximum formaldehyde could be causing <1 case per year of nasal cancer in a population of 300,000,000 US residents. Clearly, formaldehyde does not present an unreasonable risk of nasal cancer in the US, at average indoor air concentrations.” [Please see docket for details and supporting information.]
- Public Comment (University of North Carolina at Chapel Hill): “The IRIS Draft did not appreciate or misunderstood the key molecular dosimetry data using DNA adducts as the formaldehyde-specific biomarker. The EPA IRIS Draft simply used a sentence to state that ‘an increase in exogenous formaldehyde adducts has been observed in rat nasal tissue at 0.7–15 ppm’, which clearly did not appreciate or understand the significance of the critical molecular dosimetry data set.” “I appreciate that EPA agreed with formaldhyde mutagenic MOA, however, how could the IRIS Draft still perform a linear low-dose extrapolation given our clear evidence that formaldehyde interacted with DNA in a highly non-linear fashion?” “Recommendation: The EPA IRIS Draft should discuss and consider the critical molecular dosimetry data and the nonlinear dose response for DNA adducts in the risk estimates for inhaled formaldehyde” [Please see docket for details and supporting information.]
- Public Comment (ToxStrategies): “More importantly, if U.S. EPA believes that these are the two primary drivers of URT carcinogenicity and there is broad scientific consensus that there are exposures that do not increase proliferation and exposures that do not increase exogenous adducts, then it is perplexing that one of these apparently threshold mechanisms could not serve as a basis for an RfC protective against URT carcinogenicity. The application of uncertainty factors could account for any remaining uncertainty U.S. EPA has about where these thresholds occur in humans. Instead, U.S. EPA appears to accept every publication equally to the point of decision paralysis about whether there is any lower bound on exposures that do not result in proliferation or mutation-inducing adducts and therefore U.S. EPA defaults to linear no threshold cancer slope factor development.”

EPA Response (to the four public comments above): Please see prior EPA responses relating to the conclusion of an operant mutagenic MOA for formaldehyde-induced nasal cancers that is retained in the revised assessment (as supported by the peer review).

Specifically, based on the MOA analysis in Section 3.2.5 conducted according to EPA’s cancer MOA framework and as summarized during the derivation of unit risk estimates from the animal and human data in Section 5.2.1, it was concluded that both mutagenicity and cytotoxicity-induced regenerative proliferation are key events in nasal cancers caused by formaldehyde inhalation exposure. It was further concluded that there is “strong and consistent evidence for both MOAs” and that “multiple well-conducted studies demonstrate effects associated with mutagenicity (e.g., chromosomal changes) at exposure levels well below those causing cellular cytotoxicity, which is incompatible with a theory of carcinogenesis based solely upon exceedance of a cytotoxicity-based threshold.” Additionally, as stated in Section 3.2.5, “…formaldehyde may stimulate nasal epithelial cell proliferation to some extent, even in the absence of frank tissue cytotoxicity. Instead of considering independent, sequential series of key events for each of these mechanistic considerations, evidence for genotoxicity and mutagenicity, cellular proliferation (independent from tissue pathology), and cytotoxicity-induced regenerative tissue proliferation is evaluated in an integrated manner, whereby hypothesized mutagenesis and increased cellular turnover initiate and then augment URT carcinogenesis as a function of exposure duration, periodicity, and tissue dose.”

This is finally summarized in the section on “Summary and integration of mechanistic pathways” as follows: “The evidence … was assembled into a putative URT cancer MOA network highlighting the potential contributions of genotoxicity and cytotoxicity-induced regenerative proliferation (see Figure 3 24), as well as incorporating the influences of increased cell turnover independent of tissue pathology, underlying chronic inflammation and epigenetic activity ….”

The extensive EPA analyses of the nasal cancer MOA evidence resulted in the selection of a linear low-dose extrapolation in calculations of nasal cancer unit risk estimates (Section 5.2).

- Public Comment (Natural Resources Defense Council): “NRDC is concerned that the risk of SNC is not given appropriate weight; it should be included, quantitatively, in the overall cancer risk calculation. As NIEHS notes, “EPA has concluded that (1) formaldehyde is genotoxic in humans (based on studies using buccal, blood, and nasal tissues from exposed humans) and in experimental systems, (2) a genotoxic mode of action plays a role in the development of nasal tumors (SNC) and NPC, and (3) there is moderate confidence for a causal association between formaldehyde exposure and SNC risk from human studies,” (NIEHS p. 12). The hazard for SNC from formaldehyde is established by the existing science; failure to include it in an overall risk estimate may result in an underestimate of risk.”
  “NRDC agrees with EPA’s use of an ADAF-adjusted Inhalation Unit Risk (IUR) for NPC of 1.1×10-5 per ug/m3 (0.013 per ppm) (Table 2-40, p. 721). This value represents the upper-bound estimate of the increased lifetime risk of cancer from inhaling 1 ug/m3 of formaldehyde over a lifetime. The ADAF adjustments are to address exposure over a 70-year lifetime, which includes vulnerable periods of childhood, and are required by EPA’s Cancer Guidelines because the NPC cancer is due, at least in part, to a mutagenic mode of action. (p. 58).”
  “NRDC is concerned that the failure to include SNC in its overall risk finding (the inhalation unit risk, IUR), which is instead based only on the risk of NPC, will result in an underestimate of risk. Excluding both SNC and myeloid leukemia risk from the calculated IUR is pretending the risks don’t exist when in fact they are scientifically established hazards. NRDC suggests that EPA could instead present a range of overall cancer risk, from NPC-only to NPC and myeloid leukemia, and including SNC risks. This is more consistent with EPA policy to add cancer risks, and would provide both a scientific and policy honesty to EPA’s evaluation. Providing this range of overall risk values will inform decisions by regulatory agencies at local and state levels, other countries, industry, unions, communities, consumers, and others.”

EPA Response: The revised assessment emphasizes the uncertainty associated with the inability to incorporate estimates for SNC (or myeloid leukemia) risk into the IUR, and it acknowledges that cancer risk is thus expected to be underestimated by the IUR. However, there is no appropriate quantitative adjustment that can be applied for the lack of data on SNC and thus the revised assessment does not incorporate any such adjustment.

- Public Comment (Louisiana Chemical Association): “EPA was compelled to develop a IUR estimate because of its judgement that the available ‘evidence demonstrates’ that formaldehyde causes myeloid leukemia. As discussed above, LCA and other groups and scientists disagree with this designation of causality due to weak or absent causal associations, inconsistent findings, no established mode of action, etc. The methodology used by EPA to develop the IUR for myeloid leukemia further demonstrates why ‘evidence demonstrates’ is inappropriate.”
  “Because of the insufficient human and animal data base, EPA used exposure data for myeloid leukemia plus other/unspecified leukemias (which may include cases of myeloid leukemia but does include cases of non-myeloid leukemias) to develop the IUR. Due to the lack of data showing causal associations, EPA used exposure data that did not show an association with formaldehyde exposure. Because mechanistic data are insufficient to determine a MOA for formaldehyde induction of myeloid leukemia if it occurs, EPA used a default linear low-dose extrapolation, the shortcomings of which were presented under the discussion of the IUR for NPC. EPA (2002a) states that it used ‘an innovative approach’ i.e., one not yet subject to review and approval by the scientific community, to derive and present potential unit risk estimates for myeloid leukemia…EPA has developed an IUR for myeloid leukemia which seems scientifically indefensible and in which the Agency admits it has low confidence.” [Please see docket for details and supporting information.]
- Public Comment (American Chemistry Council): “For leukemia dose response assessment, the Draft Assessment uses several methods, both for deriving the inhalation unit risk (IUR) factor for myeloid leukemia and for different combinations of myeloid leukemia and other types of leukemia. Each of the derived IURs, presented in Tables 2-31 through 2-25 fall within the range of 0.03 to 0.48 (per mg/m3). No mention of relative dosimetry related to naturally occurring background concentrations of formaldehyde is included in the assessment of uncertainties in Table 2-36 or included in the section (2.2.5) of the draft assessment that was titled ‘Cancer Risk Based on Background Cancer Incidence and Internal Dose of Endogenous and Exogenous Formaldehyde.”
  “It seems that an alternative approach would be to recognize that there are considerable uncertainties in the Draft Assessment cancer risk estimates, that there is direct evidence against an association between leukemia and formaldehyde at environmentally relevant concentrations, and that the associations between formaldehyde and myeloid leukemia were not statistically significant in the study used to calculate the IUR.”
  “The 2022 draft Formaldehyde Review indicates that epidemiological data are preferred for dose-response analysis and derivation of toxicity values. In many cases, the epidemiological evidence is not suitable for use in quantitative dose-response due to insufficient exposure-response information or other issues. For formaldehyde, only animal data are adequate to describe the dose-response (i.e., threshold or ‘hockey-stick’) relationship between formaldehyde and cancer, and these are limited to nasal cancer. Despite acknowledging the evidence for LHPs is of ‘low confidence,’ EPA derives an IUR nonetheless. For specific leukemias (or other specific LHM), neither the animal toxicology nor the epidemiological evidence demonstrates a clear causal relationship and therefore deriving a slope factor or unit risk for leukemia is inappropriate.”
  “The Draft Assessment does not integrate the evidence developing IURs for nasal cancer and leukemia and fails to integrate of animal studies, toxicodynamics, toxicokinetics, or dosimetry into the modeling.”
  [Please see docket for details and supporting information.]
- Public Comment (University of California San Francisco): “EPA did not include all cancer endpoints in the estimated inhalation unit risk. EPA has appropriately determined that the evidence demonstrates that formaldehyde inhalation causes an increased risk of myeloid leukemia in humans. This determination is consistent with previous findings by International Agency for Research on Cancer (IARC) and the National Toxicology Program (NTP), with the NAS affirming the NTP conclusion. EPA, however, does not incorporate the quantitative risk of myeloid leukemia into its estimated inhalation unit risk for formaldehyde, saying that this exclusion is due to uncertainty in the interpretation of the modeling results. It is not appropriate to exclude myeloid leukemia from the quantification of formaldehyde cancer risk, regardless of the uncertainty. EPA’s National Air Toxics Assessment (NATA) has identified formaldehyde as the largest nation-wide contributor to cancer risk from air toxics. Exclusion of myeloid leukemia from calculation of the IRIS inhalation unit risk will result in consistent underestimation of cancer risk and will adversely affect risk management decisions, particularly in over-burdened communities that experience poor health status in part because of exposure to formaldehyde and other air toxics. EPA should use the results of its best modeling efforts for myeloid leukemia risk from formaldehyde inhalation and incorporate those results into its overall estimate of the inhalation unit risk for formaldehyde. Based on the current draft, that means use of the model results using data from the National Cancer Institute (NCI) study.”
- Public Comment (Environmental Defense Fund): “EDF recommends that the agency consider using the unit risk for myeloid leukemia to inform the overall cancer IUR. As stated previously, EPA did conclude that the available scientific evidence “demonstrates” that formaldehyde inhalation causes myeloid leukemia. Furthermore, as EPA stated in the Draft Assessment, the public health burden should be considered; nasopharyngeal cancer is rare and, in comparison, myeloid leukemia is more prevalent (pg. 712). EDF does not have specific recommendations for how to include the unit risk of myeloid leukemia to that of the overall cancer IUR. Rather, we ask the agency to consider the following points as it reviews comments on how to potentially update the cancer IUR. When deciding if and how the unit risk for myeloid leukemia should inform the cancer IUR, EPA should consider the existing weakness associated with the current IUR. Our specific points to consider are as follows:
  - Uncertainty with the exposure metric
  - Potential bias associated with heterogeneity among the industrial plants included in the NCI studies
  The National Academies also flagged these similar concerns about the Hauptmann et al., 2004 study, which was used to derive the IUR for nasopharyngeal cancer in the 2011 draft formaldehyde assessment in its review of the 2011 document.4 We highlight these areas of uncertainty again as we believe they would be important to consider as EPA evaluates the benefit of considering myeloid leukemia in the cancer IUR.”
  [Please see docket for details and supporting information.]
- Public Comment (Natural Resources Defense Council): “EPA acknowledges some uncertainty in the low dose-response due to the potential for endogenous formaldehyde levels to reduce the uptake of inhaled formaldehyde. Importantly, as EPA concludes, this limitation is negligent given robust scientific evidence demonstrating that formaldehyde has genotoxic, mutagenic and cytogenic mode of toxicity, thus supporting a linear low-dose extrapolation (p. 158, 171).”
  “NRDC urges EPA to consider applying ADAFs to the myeloid leukemia risk estimate. EPA did not apply ADAFs to this endpoint. NRDC supports the use of ADAF lifetime adjustments. NRDC joins the broad scientific community in advocating that this adjustment should be applied to all carcinogens, not just those that are mutagenic. This is done by Cal-EPA OEHHA, for example.”
  “NRDC is concerned that the proposed IUR will strip away much-needed health protections, as it is roughly 10-fold less protective than EPA’s 2010 draft risk estimate of 1.1 ×10-4 per ug/m3 (0.13 per ppm) based on myeloid leukemia. In fact, it sets IRIS back about a quarter-century, to the 1991 cancer risk estimate of 1.3 × 10-5 per ug/m3 that remains in the IRIS database.”
  “NRDC disagrees with excluding the risk estimates for myeloid leukemia in EPA’s overall risk estimate (the inhalation unit risk, IUR), which is instead based only on the risk of NPC. This is an especially significant oversight given that myeloid leukemia is a much more common disease than NPC, which is a very rare cancer. EPA explains its omission of the myeloid leukemia risk as due to some uncertainty and therefore a lower confidence in the exposure-response modelling results (Tox Draft p. 57). Nonetheless, the IRIS draft calculates a risk estimate for myeloid leukemia risk, of 3.4×10-5 per ug/m3 (0.042 per ppm) (Table 2-35, p. 710).”

EPA Response (to the five public comments above): Please see previous EPA responses related to the myeloid leukemia hazard decision (a judgment of evidence demonstrates is retained in the revised assessment) and quantitative estimates (a unit risk estimate for myeloid leukemia is not incorporated into the selected IUR). Both of these decisions are consistent with the advice of the consensus peer review panel, as outlined above. Note that although the results in the only study usable for quantification of myeloid leukemia were ultimately concluded to be too uncertain to support a unit risk estimate, the selected principal epidemiology study is robust for use in quantitative analysis of nasopharyngeal cancer. The assessment recognizes that, primarily due to the inability to address myeloid leukemia risk, the IUR is expected to be an underestimate (of an unknown magnitude) of the actual cancer risk.

- Public Comment (Toxicology Excellence in Risk Assessment): “EPA’s choice of dosimeter is wrong. EPA’s own text indicates that that the choice of dosimeter for the formation of tumors, either nasal pharyngeal or leukemia, is related more to the peak concentration rather than the cumulative exposure. Thus, EPA needs to develop a low dose response extrapolation on the basis of peak exposure, despite the apparent difficultly in doing so. Otherwise, EPA’s projected lifetime cancer risks are not credible.”
  “EPA should also consider the recent findings of the Alliance for Risk Assessment (ARA) Beyond Science and Decisions workshop XIII, where formaldehyde was used as an example of a new approach to dosimetry that may offer some insights.13 Simply put, this case study suggests that formaldehyde cannot penetrate the cell nucleus at low concentrations, thus supporting the threshold approach suggested by Thompson et al. (2020). In such cases, EPA (2005) cancer guidelines dictate the use of RfDs or RfCs as the basis of the low dose extrapolation rather than a linear low dose modeling.” [Please see docket for details and supporting information.]

EPA Response: The revised assessment includes an IUR based on NPC risk. EPA disagrees that peak exposure is the appropriate exposure metric for developing lifetime cancer risks for a number of reasons enumerated in the assessment (e.g., cumulative exposure is preferred; NPC risk is increased in relation to a variety of different exposure metrics; the definition of peak exposure varies across studies and not directly translatable to the chronic, lifetime exposure conditions addressed by the IUR).

## F.5 GENERAL PUBLIC COMMENTS AND PUBLIC COMMENTS NOT ADDRESSED UNDER THE TOPIC AREAS ABOVE

[Note: EPA has provided responses in Appendix F.1 to F.4 on topic areas addressed by the IRIS assessment. The comments below are either general comments not needing an EPA response or they are not relevant to the scientific analyses in the IRIS formaldehyde assessment.^46^]

- Public Comment (Natural Resources Defense Council): “Overall, we appreciate the evaluation. It is a thorough and well-reasoned scientific evaluation of the inhalation risks of formaldehyde, including both cancer and non-cancer health endpoints.”
- Public Comment (Environmental Defense Fund): “EDF applauds EPA’s Office of Research and Development’s IRIS program for a thorough, clear, well documented robust assessment that clearly demonstrates that the IRIS program heeded the advice of the National Academies of Sciences, Engineering, and Medicine (NASEM) in their 2014 and 2018 reports on the IRIS program.”
- Public Comment (University of California San Francisco): “The EPA has not allowed for adequate stakeholder engagement during the comment period. Formaldehyde is an environmental justice and affordable housing concern. Lower-income communities are disproportionately at risk of exposure to formaldehyde and resulting health effects from pressed wood products in homes built with less costly building materials. Given this, EPA should have better incorporated into the 60-day comment period opportunities for affected communities as well as academics to engage with EPA on the Formaldehyde Toxicological Review. We have stated our concerns about effectively engaging communities in the public comment process in previous comments submitted to EPA.”
- Public Comment (U.S. Poultry and Egg Association): “We wish to underscore that the formaldehyde draft assessment should be informed by the best available science and developed through a transparent and unbiased process. We are concerned that EPA has neither achieved this objective nor meaningfully conferred with USDA and FDA on pertinent issues related to animal agriculture and food safety.”
- Public Comment (American Veterinary Medical Association): “We note several federal agencies have commented on the Draft IRIS Toxicological Review of Formaldehyde (Inhalation), but we did not see comment from FDA or USDA, both of which have familiarity with the animal heath, public health, and food safety uses of formaldehyde.”
- Public Comment (United States Chamber of Commerce): “Moreover, because EPA failed to incorporate fundamental concerns around key issues during the intra-agency and interagency review process, the agency therefore should coordinate with Office of Management and Budget (OMB) to conduct a formal interagency review of the draft formaldehyde IRIS assessment that facilitates review and comment from experts at agencies familiar with use of formaldehyde across the economy (such as FDA and USDA, for example).”
- Public Comment (American Chemistry Council): “At Step 3 of its process, EPA solicits input from other federal agencies. In this case, EPA provided other federal agencies only four weeks to respond to its voluminous materials. While this time would be short under normal circumstances, EPA’s 30 days included the period from Christmas through New Year’s, a period when many in the federal government are out of the office, further reducing the actual time available for other agencies to review. Perhaps as a result of this, several federal agencies from whom responses should have been expected, did not respond. Given the lack of a clear record on the review, however, we are unable to discern why these agencies did not respond. For this reason, and others discussed below, EPA should reengage with other federal agencies to ensure it has obtained their considered opinions.”
  “EPA has not sought meaningful comment on draft charge questions and peer review committee task, and EPA and NASEM sequencing of public comment, 2022 Draft Assessment revisions, and selection of reviewers undermines the rigor of the peer review.”
  “EPA’s draft peer review charge questions^191^ unduly narrow the scope of the review, raising key scientific, legal, and policy issues on the quality and independence of the peer review process. For example, there are no questions regarding the 2011 NASEM recommendations on the 2010 Draft Assessment.”
  “With regard to the lack of transparency, EPA has not docketed its responses to the interagency comments on the 2022 Draft Assessment. The failure to document any changes to the 2022 Draft Assessment (including its appendices) based on interagency comment further hamstrings the public’s ability to comment on this complex and lengthy document.”
  “The interagency review process conducted on the 2022 Draft Assessment demonstrates why a more structured interagency review process is appropriate, especially for assessments, such as the 2022 Draft Assessment, which have the potential to cause major regulatory and other impacts if they are adopted and used in subsequent regulatory actions. Submitting draft assessments for review under E.O. 12866 as “significant guidance documents” would result in a process that is more transparent, responsive, accountable, deliberate, and advantageous for several reasons.”
  “Consistent with the prior NAS review of this assessment and the valuable NAS feedback to improve the IRIS process as well as EPA’s legal and scientific requirements, ACC and the Panel recommend the following steps:
  1. Request the Office of Management and Budget to conduct a formal interagency review for the draft formaldehyde IRIS assessment and charge questions prior to their release for public comment.
  2. Publish and respond to interagency comments on draft charge questions prior to commencing the public comment period or peer review process.
  3. Consistent with EPA^5^ and White House policies,^6^ take public comment on draft charge questions before initiating the peer review. In light of these clear directives on sequencing, EPA and NAS should evaluate those comments prior to selection of the panel “so that appropriate expertise is included to address all charge questions,” and, if appropriate, re-open the nomination process.
  4. EPA should incorporate the recommended charge questions (Appendix 1) and those received during the public comment period and update the committee task.
  5. EPA should not restrict the committee’s task to “responding only to the materials provided by the EPA”.”
  [Please see docket for details and supporting information.]
- Public Comment (Anonymous): “This comment seeks to highlight for EPA as well as reviewers from the National Academy of Sciences, Engineering, and Medicine the content of relevant feedback in EPA’s general IRIS docket (http://www.regulations.gov/docket/EPA-HQ-ORD-2014-0211), for which the Agency has directed comments on the IRIS process in recent years (https://iris.epa.gov/Dockets/). Attached are examples of submissions which may be relevant to the review of the draft formaldehyde assessment.” [Please see docket for details and supporting information.]
- Public Comment (Anonymous): “Also attached are several economic, legal, public policy, and editorial publications highly relevant to this assessment and the IRIS process. [Graham and Liu 2014; Williams 2019; Graham 2006; Logomasini 2020; Logomasini 2019; Dourson 2018].” [Please see docket for details and supporting information.]
- Public Comment (American Chemistry Council): EPA has already taken steps that at a minimum raise questions regarding the appearance of a lack of impartiality. While NASEM has not released a provisional list of panel members who will review the 2022 Draft Assessment, the assessment cites multiple publications coauthored by the Staff Officer with well-documented involvement with the IRIS program, this assessment, the response to the previous NASEM recommendations, and EPA advocacy on this matter. Even if not explicitly prohibited by the above cited NASEM policy, participation of this Staff Officer raises significant issues, particularly as the 2022 Draft Assessment relies on the Staff Officer’s publications violates EPA policies on independence and reviewing one’s own work. In addition, the solution provided by NASEM’s policies for a conflicted or biased panelist who nonetheless is the only source of needed expertise is to “balance” that individual’s perspective on the panel, a remedy that is not possible in the case of a conflicted Staff Officer.”
  “The OMB Peer Review Guidance cautions agencies to “avoid repeated use of the same reviewer on multiple assessments unless his or her participation is essential and cannot be obtained elsewhere.” EPA Peer Review Handbook uses similar language: “The principle is to avoid the repeated use of the same reviewer on multiple assessments unless his/her participation is essential and the expertise cannot be obtained elsewhere.”^180^ Despite this clear guidance, the responsible Staff Officer has stated unequivocally that the EPA sponsored NASEM committee will include members from the previous 2011 NASEM committee that reviewed the 2010 draft IRIS formaldehyde assessment.”
- Public Comment (Roger O. McClellan): “I request that EPA finalize the IRIS Formaldehyde document without the involvement of a committee formed by the National Academies of Science, Engineering and Medicine… The proposed involvement of a NASEM committee in bringing the IRIS document to closure is inappropriate. The NASEM modus operandi with the majority of committees deliberations conducted in closed sessions, out of view of the public, without detailed transcripts is not consistent with EPA’s requirements that all EPA Advisory Committee activities be open to the public with the opportunity for public input at each meeting with all proceedings documented and transcripts available to interested parties. The Task Order agreement executed between EPA and the NASEM in the Fall of 2021 should be canceled by mutual agreement of both parties… If you, as EPA Administrator, determine that finalization of the IRIS Document will benefit from input from a Scientific Advisory Committee of qualified experts, you have the legal authority to appoint such a Committee to function with oversight by a qualified EPA Federal Government Employee…In my opinion, the EPA does not need any further advice from the NASEM on this matter. I submit that with each NASEM review there is a potential for Committee members to offer more detailed prescriptive advice for EPA to follow to reach the regulatory conclusions the NASEM Committee members would like from EPA.”
  [Please see docket for details and supporting information.]
- Public Comment (Formacare): “We are concerned about the draft IRIS Risk Assessment as it is not consistent with the scientific and regulatory conclusions on formaldehyde in the European Union.”
  “In the IRIS Risk Assessment, calculated unit risk estimates were in the range of 6.4 × 10^−6^ and 3.4 × 10^−5^ per μg/m^3^ for the respective cancer types and reference concentrations (RfCs) for non-cancer health effects were derived in the order of 0.001-0.01 mg/m^3^. It is worth noting that, as given in the WHO indoor guidance documentation from 2010 and updated in 2017, the formaldehyde concentration in exhaled air from humans is just in the same range: “Human exhaled air contains formaldehyde in concentration in the order of 0.001–0.01 mg/m^3^, with an average value of about 0.005 mg/m^3^”. Formacare would recommend putting the unit risk estimates and RfCs for the respective diseases in perspective with the respective prevalence considering actual exposures. This could avoid that the assessment misses capturing the possible risk from formaldehyde exposure in indoor environments and at the workplace.”
- Public Comment (United States Chamber of Commerce): “Additionally, the exposure limits and dose response criteria (i.e., Reference Concentrations and Inhalation Unit Risk Factors) proposed are 100 to 1000 times more stringent than the exposure limits/dose response criteria recently established or under consideration in the European Union. These ‘protective’ concentration limits are similar to concentrations in human breath and are at or below the background formaldehyde concentrations in rural air.”
- Public Comment (Independent Lubricant Manufacturers Association): “While ILMA members understand EPA’s interest in protecting consumers and workers, their experience is that the use of formaldehyde-release biocides have resulted in few issues over decades of use. In part, this is due to an evolving industrial landscape, including increased ventilation, PPE, and safety protocols to reduce well-known and studied hazards, like those caused by the proliferation of microbiological toxins. MWF companies are concerned that, by EPA’s ill-supported Draft Assessment, one of the most powerful tools for worker protection will be effectively compromised.”
- Public Comment (U.S. Poultry and Egg Association): “From our initial review of EPA’s formaldehyde assessment, we note that there is no descriptive reference or acknowledgement of the presence, use, benefit or possible hazards associated with formaldehyde applications in the animal agriculture sector.”
- Public Comment (American Chemistry Council): On p. 3-29 ‘An overall RfC for formaldehyde of 0.007 mg/m^3^ was selected. This value is within the narrow range (0.006-0.009 mg/m^3^) of the group of respiratory system-related RfCs, which together are interpreted with High confidence (sensory irritation, pulmonary function, allergy-related conditions, and current asthma prevalence or degree of control.’ EPA guidelines allow a considerable degree of freedom in identifying LOAELs, NOAELs, modeling dose-response, and selecting uncertainty factors. The statement above, however, gives the appearance of conclusions being targeted to a pre-determined number.”
  “Inappropriately the Draft Assessment does not justify the large quantitative differences in EPA’s hazard and dose-response assessments when compared to recently published exposure guidelines and limits by both WHO and the European Commission, respectively. Each of these authoritative bodies derived safe exposure levels up to three orders of magnitude higher than the safe exposure limits (RfCs and IURs) presented in the Draft Assessment.”
  “As such, the Draft IRIS Assessment should be benchmarked against competent authority evaluations [WHO, SCOEL, ECHA] performed under similar assessment guidelines. Additionally, any substantial deviations from other competent authorities conclusions must be documented and discussed in the Draft IRIS Assessment. Any further revisions to the Draft Assessment, must address the major differences between the derived no-effect levels (DNELs) and Occupational exposure limits (OELs) when compared to the RfCs and IURs proposed.”
  “The Draft Assessment reaffirms the oral RfD developed in 1990 and is currently on IRIS. This exposure limit raises public concern unduly with little likelihood of any recognizable health benefits…A simple ground truthing demonstrates the inappropriate degree of conservatism in the medium confidence RfD. It is well known that formaldehyde is an endogenously produced natural product of metabolism. In addition, there are many studies of the naturally occurring concentrations of formaldehyde in food. For example, in their evaluation of the literature regarding background concentrations of formaldehyde in food, the European Food Safety Authority (EFSA, 2014) calculated the mean concentration of formaldehyde in foods to be 100 mg/kg. Assuming an average human body weight of 70 kg and the oral RfD of 0.2 mg/kg/day, the safe oral dose is 14 mg/person/day. Assuming consumption of 1 kg of food/day/70 kg human, the average human ingests 100 mg formaldehyde/day. As such, our normal diet exceeds the safe exposure level by 7 times the allowable limit. Clearly, this does not reflect actual risk, is not derived from the best available science, is overly conservative, and unnecessarily alarmist.”
  “In addition, EPA has signaled that, in the formaldehyde risk evaluation under the amended Toxic Substances Control Act (TSCA), it “plans to include information developed from the draft IRIS hazard and dose response assessment.”8 The push to use draft IRIS information in a regulatory setting without finalizing the assessment or addressing comments on the underlying work product runs contrary to EPA policies and ACC comments on the scoping document. It also suggests that the Agency’ rush to deploy the draft could short-circuit a rigorous peer review process.”
  “U.S. EPA’s use of draft assessment violates statutory requirements for “Best Available Science”…Perhaps most concerning, U.S. EPA has signaled that, in its forthcoming draft and final formaldehyde risk evaluation under TSCA, it “plans to include information in a regulatory setting prior to finalizing the assessment, by incorporating both public and peer review comments, runs contrary to EPA policies and would render superfluous both public comment and a rigorous peer review process.”
  “EPA’s failure to proactively discourage use of draft assessment violates agency policies. Failure to proactively prevent use of the draft IRIS assessment by those inside and outside the Agency would contradict long-standing EPA policies on peer review, information quality, and intergovernmental collaboration.” [Please see docket for details and supporting information.]

42 Comments that have been truncated or which have additional details or supporting information in the docket are noted as such in the sections below [Disclaimer: while EPA made every effort to compile accurately and comprehensively the submitted public comments in these courtesy tables, it is possible some information could be missing or inaccurate. Footnote callouts were deleted, and a few minor grammatical corrections were made to some comments for clarity. The EPA docket is the primary source that should be consulted for comments on this assessment.]

43 If newly identified studies that meet the assessment PECO criteria are found by, or brought to the attention of, the panel during the peer review, EPA asks the panel to judge whether the studies would significantly alter key conclusions (e.g., the draft RfC or IUR) and, if so, how. For any studies judged to significantly alter key conclusions, please recommend where and how such studies should be incorporated in the final assessment.

44 https://nap.nationalacademies.org/catalog/26289/review-of-us-epas-ord-staff-handbook-for-developing-iris-assessments (2022) https://nap.nationalacademies.org/catalog/25086/progress-toward-transforming-the-integrated-risk-information-system-iris-program (2018) https://nap.nationalacademies.org/catalog/18764/review-of-epas-integrated-risk-information-system-iris-process (2014)

45 For all non-cancer health effects for which the evidence demonstrates or indicates an effect is caused (or likely to be caused) in humans by formaldehyde inhalation, the exposure circumstances that may be necessary for this to occur are estimated through subsequent dose-response analysis. This phrase is included to signify the linkage between hazard identification and dose-response analysis.

46 IRIS assessments are not risk assessments and they do not address exposure assessment or risk management considerations. These are the purview of other EPA program and regional offices, and thus responses are not provided to these comments. Responses are also not provided to comments related to EPA, IRIS, or NASEM processes or policies. EPA draws independent scientific conclusions based on the evidence, which can differ from conclusions by others (see Appendix G for a summary). IRIS assessments do not include evaluations of such potential differences, and thus, responses to comments of this nature are not provided.