# APPENDIX D DOSE-RESPONSE ASSESSMENT SUPPLEMENT

The technical detail on dose-response evaluation and determination of points of departure (POD) for relevant toxicological endpoints are provided in this Appendix for Noncancer (Appendix D.1) and Cancer (Appendix D.2) endpoints. Some of the endpoints were modeled using the U.S. EPA’s Benchmark Dose Software (BMDS, version 3.3). The common practices used in evaluating the model fit and selecting the appropriate model for determining the POD, as outlined in the Benchmark Dose Technical Guidance Document (U.S. EPA, 2012) were used^21^. For some data, alternative methods were used, and these are noted as necessary in the summary of the modeling results.

## D.1 DOSE-RESPONSE ANALYSIS FOR NONCANCER HEALTH EFFECTS

A thorough understanding of the exposure-response functions for any association between exposure and health outcomes supports both the derivation of the traditional toxicity values (e.g., RfC) as well as potentially allowing for the estimation of risk above and below those values, and thus provides a more comprehensive understanding of the effects of formaldehyde exposure on various health outcomes. The following details on the estimation of points of departure for the derivation of candidate reference concentrations (cRfCs) are provided to support the derivation of toxicity values as well as to directly inform the potential computation of benefits analyses which require detailed information describing the shape of the exposure-response function across a range of exposures. Such benefits analyses may be used to support a variety of rulemakings.

### D.1.1 Sensory Irritation

#### Estimates from Observational Epidemiology Studies

##### Hanrahan et al. (1984)

Hanrahan et al. (1984) conducted a cross-sectional study and reported a concentration-response relationship for the prevalence of ocular discomfort (i.e., burning eyes/eye irritation) in a study of 61 teenage and adult residents of mobile homes in Wisconsin. In-home formaldehyde measurements were obtained for all participants, and measured formaldehyde levels (average of two approximately 1-hour air samples^22^—one from the kitchen or living room and one from a bedroom) were used to characterize average in-home exposures.

Hanrahan et al. (1984) reported that prevalent symptoms^23^ of burning eyes and eye irritation were significantly associated with in-home formaldehyde exposures, and the authors provided a graphical representation of the best-fitting logistic regression model results of predicted prevalence of “burning eyes” for exposures at 100 ppb increments from 100 to 800 ppb. From inspection of this graph, EPA determined the prevalence of burning eyes predicted at 100 ppb is approximately 4%. While the published exposure-response results were shown truncated at 100 ppb, (Hanrahan et al., 1984) reported that exposures ranged from <100 ppb to 800 ppb, and the indoor median formaldehyde concentration was 160 ppb. The reconstruction of that underlying functional form can show the results of the (Hanrahan et al., 1984) model extended below 100 ppb.

Figure D-1 Regression of prevalence of “burning eyes” versus indoor formaldehyde concentration (ppm) in mobile homes (approximately 1-hour air samples)

Dashed lines show upper and lower 95th percentile confidence intervals on model results.

In Figure D-1, the dependent variable is displayed as a predicted percentage prevalence of burning eyes. However, the general epidemiologic method used to model prevalence data is logistic regression, which predicts the log odds of prevalence, which the authors then transformed to prevalence for graphing. In order to describe the underlying functional form of the results displayed, EPA converted the prevalence data back to prevalence odds. Table D-1 shows the prevalence values which EPA visually estimated from the plot, as well as the associated prevalence odds, which EPA calculated as estimated prevalence divided by the complement of estimated prevalence, that is p/(1-p). Figure D-2 plots the estimated prevalence odds against the residential concentration of formaldehyde.

Table D-1 Concentration-response information for the central estimate of the effect extracted from (Hanrahan et al., 1984

Residential formaldehyde concentration (ppm) | Prevalence(p) | Prevalence odds (p/[1-p])
0.1 | 0.038 | 0.039
0.2 | 0.182 | 0.223
0.3 | 0.362 | 0.567
0.4 | 0.525 | 1.104
0.5 | 0.655 | 1.897
0.6 | 0.735 | 2.777
0.7 | 0.806 | 4.159
0.8 | 0.846 | 5.508

Figure D-2 Plot of the central estimate of the prevalence odds by residential concentration-response information from Table D-1

In order to describe the underlying functional form of the model-predicted results from (Hanrahan et al., 1984), EPA fit polynomial trend lines from linear up to cubic functions with the intercept fixed at a background prevalence of burning eyes of 3% (prevalence odds of 0.0309)^24^ (using Microsoft Excel) to the discrete prevalence odds data in Figure D-2 and found that a third-degree polynomial function fit with an R^2^ value of 0.9994. This indicates nearly a perfect fit to the published model results. Such a high value of R^2^ would not have been achieved from analysis of the raw data (unavailable), but the objective here was to recreate the functional form of the modeled data presented by (Hanrahan et al., 1984). The following describes the functional form for the prevalence odds:

(p)/(1 − p) = 2.3015 * ( e x p o s u r e )^3^ + 7.6683 * ( e x p o s u r e )^2^ − 0.7233 * ( e x p o s u r e ) + 0.0309 (D-1)

Table D-2 shows the prevalence values for the upper bound on the central estimate of the published concentration-response function, which EPA visually estimated from the plot, as well as the associated prevalence odds, which EPA calculated as estimated prevalence divided by the complement of estimated prevalence, that is p/(1-p). Figure D-3 plots the estimated prevalence odds against the residential concentration of formaldehyde.

Table D-2 Concentration-response information for the upper bound on the central estimate of the effect extracted from (Hanrahan et al., 1984

Residential formaldehyde concentration (ppm) | Prevalence (p) | Prevalence odds (p/[1-p])
0.1 | 0.18 | 0.22
0.2 | 0.35 | 0.54
0.3 | 0.55 | 1.22
0.4 | 0.74 | 2.85
0.5 | 0.84 | 5.25
0.6 | 0.91 | 10.11
0.7 | 0.94 | 15.67
0.8 | 0.96 | 24.00

Figure D-3 Plot of the upper bound on the central estimate of the prevalence odds by residential concentration-response information from Table 2

In order to describe the underlying functional form of the model-predicted results from Hanrahan et al. (1984), EPA fit polynomial trend lines from linear up to cubic functions with the intercept fixed at zero (using Microsoft Excel) to the discrete prevalence odds data in Figure D-3 and found that a third-degree polynomial function fit with an R^2^ value of 0.9995. This indicates nearly a perfect fit to the published model results. The following describes the functional form for the prevalence odds:

(p)/(1 − p) = 56.551 * ( e x p o s u r e )^3^ − 10.388 * ( e x p o s u r e )^2^ + 2.0796 * ( e x p o s u r e ) + 0.003 (D-2)

Selecting a benchmark response (BMR) for the derivation of a reference concentration (RfC) involves making judgments about the statistical and biological characteristics of the data set. A BMR representing an extra risk of 10% is generally recommended as a standard reporting level for quantal data. Biological considerations may warrant the use of a BMR of 5% or lower for some types of effects (e.g., frank effects), or a BMR greater than 10% (e.g., for early precursor effects) as the basis of the point of departure (POD) for a reference value (U.S. EPA, 2012).

EPA calculated the concentration at which a 10% extra risk of “burning eyes” would have been observed in these data using the polynomial functions for the main effect to estimate the BMC and for the upper-bound to estimate the BMCL. In this derivation, 10% extra risk is the benchmark response (BMR) and the BMC and BMCL for a 10% BMR are noted as the BMC_10_ and BMCL_10_. Note that in Hanrahan et al. (1984), the prevalence of “burning eyes” was similar to that of “eye irritation.” As there is little information available in the literature to estimate the background prevalence of “burning eyes,” the background prevalence of “burning eyes” was estimated at 3% (in the absence of formaldehyde exposure) based on the prevalence of “eye irritation.” A background prevalence of 3% was considered to be a reasonable estimate. Sensitivity analyses using a background prevalence of 1% and 2% were also evaluated and yielded BMC and BMCL estimates.^25^

Because the extra risk is a function of the prevalence in the exposed (P_Exposed_) and the prevalence in the unexposed (P_Unexposed_) was estimated at 3%, EPA derived P_Exposed_ for 10% extra risk above background.

Extra Risk = 0.10 = [P_Exposed_ − P_Unexposed_] / [1 − P_Unexposed_] and P_Unexposed_ = 0.03 , then P_Exposed_ = 0.127. (D-3)

Because the exposure-response function from Hanrahan et al. (1984) is in terms of the prevalence odds, that value is derived based on P_Exposed_ = 0.127. Thus, the prevalence odds = [P_Exposed_]/[1-P_Exposed_] = 0.145. To derive the BMC, solve for the exposure value, which yields prevalence odds of 0.145:

0.145 = 6.1949 * ( e x p o s u r e )^3^ + 3.7689 * ( e x p o s u r e )^2^ + 0.0309 * ( e x p o s u r e ) + 0.03 (D-4)

Of the three roots, only one is within the exposure range of the data.

Exposure = 0.153 ppm formaldehyde = 0.188 mg/m^3^ formaldehyde (see footnote^26^)

To derive the interim BMCL, solve for:

0.145 = 56.551 * ( e x p o s u r e )^3^ − 10.388 * ( e x p o s u r e )^2^ + 2.0796 * ( e x p o s u r e ) + 0.03 (D-5)

Of the three roots, only one is within the exposure range of the data.

Exposure = 0.0706 ppm formaldehyde = 0.0868 mg/m^3^ formaldehyde

The BMC_10_ is 0.188 mg/m^3^. The BMCL_10_ is 0.0868 mg/m^3^.

(Liu et al., 1991) [underlined: combined with] (Hanrahan et al., 1984)

Hanrahan et al. (1984) provided graphical dose-response information of formaldehyde concentrations of 0.1 ppm to 0.8 ppm and the prevalence of “burning eyes” (sensory irritation) which EPA extracted for modeling. Liu et al. (1991) also provided graphical dose-response information at lower exposure levels using a cumulative exposure metric of ppm-hours during the weeklong sampling period for the prevalence of “burning eyes”. The 2014 National Research Council (NRC) report recommended that dose-response estimation be based on data from compatible studies of similar exposure and outcome when feasible and the specific idea to estimate the dose-response function from the combination of these two studies was recommended by NASEM (NASEM, 2023). The data from (Liu et al., 1991) and (Hanrahan et al., 1984) complemented each other, although several assumptions were necessary to fit the two related datasets together.

In order to convert these cumulative exposure metrics to concentration values, the duration time needed to be divided out. (Liu et al., 1991) does not specifically say what the duration time was, however, (Liu et al., 1991) noted that “[f]or a person who spends 60% of the time inside his or her own home, a weekly HCHO exposure of 7 ppm-hours can be translated into a weekly average HCHO concentration of 0.07 ppm. From this statement, EPA assumed that (Liu et al., 1991) expected that their study subjects spent 60% of their week inside their homes which is 100.8 hours per week. (Liu et al., 1991) graphical results showed the prevalence of “burning eyes” as a function of cumulative formaldehyde concentration for three categories of exposure: 0–7.0 ppm-hours; 7.0–12.0 ppm-hours; and >12.0 ppm-hours. Dividing the three categories of exposure by 100.8 hours, the three exposure categories are: 0.01-0.06944 ppm; 0.06944-0.1195 ppm; and >0.1195 ppm.

More granular exposure data from the same study was published in (Sexton et al., 1986) which provided graphical data for the two seasons when homes were sampled: summer (Jul/Aug) and winter (Feb/Mar) although the increments of the exposure categories did not match up evenly with the increments of exposure from (Liu et al., 1991). For example, the increment of exposure from (Sexton et al., 1986) were shown in a histogram per 0.025 ppm from zero to > 0.45 ppm in Summer and to 0.35 ppm in winter. While the graphic of exposure data in Figure 3 of (Sexton et al., 1986) shows the lowest exposure at zero, Liu et al. (1991) reported that the limit of detection was 0.01 ppm and (Sexton et al., 1986) reported that the maximum exposure was 0.464 ppm which provides an upper bound on the summer exposure category of “>0.45 ppm.” Similarly, for Winter, the minimum exposure was 0.017 ppm and the maximum was 0.314 ppm. EPA extracted data from Figure 3 in (Sexton et al., 1986) to estimate the percentage of mobile homes corresponding to the three exposure categories in (Liu et al., 1991). This information is included in Table D-3 to describe the mid-point of each exposure category and then the estimated exposure for each group from (Liu et al., 1991) is the average of the exposure in each group from (Sexton et al., 1986) weighted by the estimated number of homes for each exposure group in (Sexton et al., 1986).

Table D-3 Extracted data from (Liu et al., 1991 and (Sexton et al., 1986 used to estimate additional data point for dose-response of sensory irritation

Season | Exposure group (ppm) from Liu et al. (1991) | Exposure group (ppm) from (Sexton et al., 1986) | Exposure group mid-point (ppm) | Estimated number of homes in (Sexton et al., 1986) intervals^a^ | Number of homes per Liu et al. (1991) intervals | Estimated group exposure^b^ in Liu et al. (1991) intervals (ppm) | Prevalence of “Burning eyes” by exposure category in Liu et al. (1991) | Prevalence odds; (p/[1-p])
Summer | 0.01-0.0694 | 0.01-0.025 | 0.0175 | 40 | 315 | 0.0431 | 13.3% | 0.153
Summer | 0.01-0.0694 | 0.025-0.05 | 0.0375 | 160 | 315 | 0.0431 | 13.3% | 0.153
Summer | 0.01-0.0694 | 0.05-0.0694 | 0.05972 | 115 | 315 | 0.0431 | 13.3% | 0.153
Summer | 0.0694-0.119 | 0.0694-0.075 | 0.0722 | 33 | 192 | 0.0906 | 17.1% | 0.206
Summer | 0.0694-0.119 | 0.075-0.1 | 0.0875 | 109 | 192 | 0.0906 | 17.1% | 0.206
Summer | 0.0694-0.119 | 0.1-0.119 | 0.1095 | 50 | 192 | 0.0906 | 17.1% | 0.206
Summer | 0.1195-0.464 | 0.119-0.125 | 0.12205 | 16 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.125-0.15 | 0.1375 | 40 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.15-0.175 | 0.1625 | 33 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.175-0.20 | 0.1875 | 17 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.20-0.225 | 0.2125 | 15 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.225-0.25 | 0.2375 | 7 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.25-0.30 | 0.275 | 9 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.30-0.35 | 0.325 | 9 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.35-0.40 | 0.375 | 5 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.40-0.45 | 0.425 | 3 | 156 | 0.1943 | 21.4% | 0.272
Summer | 0.1195-0.464 | 0.45-0.464 | 0.457 | 2 | 156 | 0.1943 | 21.4% | 0.272
Winter | 0.01-0.06944 | 0.017-0.025 | 0.021 | 8 | 205 | 0.04748 | 10.8% | 0.121
Winter | 0.01-0.06944 | 0.025-0.05 | 0.0375 | 99 | 205 | 0.04748 | 10.8% | 0.121
Winter | 0.01-0.06944 | 0.05-0.06944 | 0.05972 | 98 | 205 | 0.04748 | 10.8% | 0.121
Winter | 0.06944-0.1195 | 0.06944-0.075 | 0.0722 | 28 | 208 | 0.09115 | 14.7% | 0.172
Winter | 0.06944-0.1195 | 0.075-0.1 | 0.0875 | 126 | 208 | 0.09115 | 14.7% | 0.172
Winter | 0.06944-0.1195 | 0.1-0.119 | 0.1095 | 54 | 208 | 0.09115 | 14.7% | 0.172
Winter | 0.1195-0.314 | 0.119-0.125 | 0.122 | 17 | 110 | 0.1698 | 20.6% | 0.259
Winter | 0.1195-0.314 | 0.125-0.15 | 0.1375 | 31 | 110 | 0.1698 | 20.6% | 0.259
Winter | 0.1195-0.314 | 0.15-0.175 | 0.1625 | 26 | 110 | 0.1698 | 20.6% | 0.259
Winter | 0.1195-0.314 | 0.175-0.2 | 0.1875 | 10 | 110 | 0.1698 | 20.6% | 0.259
Winter | 0.1195-0.314 | 0.2-0.225 | 0.2125 | 10 | 110 | 0.1698 | 20.6% | 0.259
Winter | 0.1195-0.314 | 0.225-0.25 | 0.2375 | 10 | 110 | 0.1698 | 20.6% | 0.259
Winter | 0.1195-0.314 | 0.25-0.30 | 0.275 | 3 | 110 | 0.1698 | 20.6% | 0.259
| | 0.30-0.314 | 0.307 | 3

a Estimated from the extracted % of mobile homes in Figure 3 of (Sexton et al., 1986) and rounded to whole numbers.

b Estimated exposure for each group from Liu et al. (1991) is the average of the exposure in each group from Sexton et al. (1986) weighted by the estimated number of homes for each exposure group in Sexton et al. (1986).

c A conversion of 1 ppm = 1.23 mg/m^3^ formaldehyde is used.

In Figure D-4 below, EPA combined the eight points from the dose-response data from (Hanrahan et al., 1984) with the six additional points from (Liu et al., 1991), which shows that the two sets of reconstructed dose-response data overlapped between 0.1 and 0.2 ppm formaldehyde concentration.

Figure D-4 Plot of the prevalence odds by residential concentration-response information from the central estimate of from Hanrahan et al. (1984) combined with complementary information from the central estimate of from Liu et al. (1991)

Blue circles (Hanrahan et al., 1984); Red squares ‘Summer’ Liu et al. (1991); Green triangles ‘Winter’ Liu et al. (1991).

Assuming a background prevalence of “burning eyes” of 3%, EPA fit a cubic polynomial function with the intercept fixed at the log-odds of 0.03 (0.0309), to the discrete prevalence odds data in Figure D-4 and found that a third-degree polynomial function fit with an R^2^ value of 0.998 (see Figure D-5). The following formula describes the functional form for the prevalence odds:

(p)/(1 − p) = 7.8077 * ( e x p o s u r e )^3^ + 1.6517 * ( e x p o s u r e )^2^ + 0.7104 * ( e x p o s u r e ) + 0.0309 (D-6)

Figure D-5 Plot of the prevalence odds by residential concentration-response information from the central estimate of from (Hanrahan et al., 1984) combined with information from the central estimate of from (Liu et al., 1991) with third degree polynomial function fit to these data

EPA used a BMR of 10% extra risk of “burning eyes” and calculated the concentration at which a 10% extra risk of “burning eyes” would have been observed in these data using the polynomial functions for the main effect to estimate the BMC_10_. EPA calculated the concentration at which a 10% extra risk of “burning eyes” would have been observed in these data using the polynomial functions for the main effect to estimate the BMC. Since extra risk is a function of the prevalence in the exposed (P_Exposed_) and the prevalence in the unexposed (P_Unexposed_), which was estimated at 3%, EPA derived P_Exposed_ for 10% extra risk above background.

Extra Risk = 0.10 = [P_Exposed_ − P_Unexposed_] / [1 − P_Unexposed_] and P_Unexposed_ = 0.03 , then P_Exposed_ = 0.127. (D-7)

Because the exposure-response function from Hanrahan et al. (1984) is in terms of the prevalence odds and the prevalence odds were also estimable from Liu et al. (1991), the BMC_10_ is derived based on P_Exposed_ = 0.127. Thus, the prevalence odds = [P_Exposed_]/[1-P_Exposed_] = 0.145. To derive the BMC, solve for the exposure value, which yields prevalence odds of 0.145:

0.145 = 7.8077 * ( e x p o s u r e )^3^ + 1.6517 * ( e x p o s u r e )^2^ + 0.7104 * ( e x p o s u r e ) + 0.0309 (D-8)

Of the three roots, only one is within the exposure range of the data.

Exposure = 0.1141 ppm formaldehyde = 0.1403 mg/m^3^ formaldehyde^27^

The BMCL_10_ for the combined data from (Hanrahan et al., 1984) and (Liu et al., 1991) is 0.1403 mg/m^3^ formaldehyde. EPA used the data extracted from the Hanrahan study to estimate a BMC_10_ and BMCL_10_ for sensory irritation since Hanrahan et al. (1984) provided the upper bound of the risk estimates which could be used to estimate the BMCL_10_. Liu et al. (1991) did not report the confidence intervals for the estimated dose-response so no BMCL_10_ for the combined data is possible.

#### Estimates from Controlled Exposure Studies in Humans

##### Kulle et al. (1993, 1987)

Modeling results are presented that support the derivation of PODs for sensory irritation based on two controlled human exposure studies. Kulle et al. (1993) reanalyzed results of a study of eye, nose, and throat irritation among participants exposed to 0, 0.5, 1.0, 2.0, and 3.0 ppm for 3 hours once a week with exposure order randomly assigned (Kulle et al., 1987). The results of the different modeling approaches are summarized in Table D-4 and explained below.

Table D-4 Modeling summary for irritation symptoms in (Kulle et al., 1987; Kulle, 1993)

Approach | Endpoint^a^ | Selected model^b^ | BMC^c^ (ppm) | BMCL (95%) ppm | BMCL (99%) ppm | Notes
CatReg | Combined^d^ Eye Irritation or Nose/Throat Irritation | Probit | 0.56 | 0.42 | 0.36 | Selected POD
CatReg | Eye Irritation | CLogLog | 0.80 | 0.57 | 0.47
CatReg | Nose/Throat Irritation | - | - | - | - | Model fit not acceptable^d^
BMDS | Eye Irritation | Probit | 0.69 | 0.50 | 0.44
BMDS | Nose/Throat Irritation | Multistage 3° | 1.27 | 0.45 | 0.27 | Large BMC: BMCL ratio

a Eye irritation results throughout this table reflect modeling of males and females combined. Nose/throat irritation results throughout this table reflect modeling of females only given the negative slope observed for males.

b The selected model for each approach and endpoint was the viable model with the lowest AIC (see details below).

c BMC and BMCL are termed ERC and LERC in CatReg. In both, a BMR of 10% extra risk was used for the modeling.

d The preferred model used eye irritation data to predict the slope and combined eye and nose/throat irritation data for the intercept. A second modeling combination using nose/throat irritation for the slope and combined irritation data for the intercept yielded a slightly higher POD of 0.48 ppm at the 99^th^ percentile (see details below). The selected CatReg model results were preferred primarily due to the lower POD, although the BMC/BMCL ratio for these results was also lower, indicating a narrower confidence interval and a lower level of uncertainty.

The datasets modeled from this study (Kulle et al., 1987; Kulle, 1993) are presented in Table D-5 below.

Table D-5 Incidence and severity of sensory irritation symptoms in humans after controlled formaldehyde exposure

Sensory irritation endpoint | Formal-dehyde (ppm) | Symptom prevalence and severity^a^
Sensory irritation endpoint | Formal-dehyde (ppm) | Males | | | | Females
Sensory irritation endpoint | Formal-dehyde (ppm) | None | Mild | Moderate | Severe | None | Mild | Moderate | Severe
Eye Irritation | 0 | 9/10 | 1/10 | – | – | 9/9 | – | – | –
Eye Irritation | 0.5 | 4/4 | – | – | – | 6/6 | – | – | –
Eye Irritation | 1 | 8/10 | 2/10 | – | – | 6/9 | 2/9 | 1/9 | –
Eye Irritation | 2 | 5/10 | 2/10 | 3/10 | – | 4/9 | 4/9 | 1/9 | –
Eye Irritation | 3 | – | 3/6 | 3/6 | – | -- | 2/3 | 1/3 | –
Nose/Throat Irritation | 0 | 9/10 | 1/10 | – | – | 7/9 | 2/9 | – | –
Nose/Throat Irritation | 0.5 | 4/4 | | -- | -- | 5/6 | 1/6 | -- | --
Nose/Throat Irritation | 1 | 9/10 | 1/10 | -- | -- | 9/9 | | -- | --
Nose/Throat Irritation | 2 | 8/10 | 2/10 | -- | -- | 4/9 | 5/9 | -- | --
Nose/Throat Irritation | 3 | 6/6 | | -- | -- | 1/3 | 2/3 | -- | --

a The authors also report results for a “symptom score difference” (pre- and post-exposure), pooling results across severity levels; however, these pooled data were not preferred for use quantitatively without information on the underlying within-subject severity information at both timepoints or the score calculations.

###### CatReg Model Forms

CatReg offers two choices of models, Model 1 (cumulative odds model) and Model 2 (unrestricted cumulative model). For additional details see the CatReg User guide (U.S. EPA, 2017).

The Cumulative Odds Model is described by the following equation:

Pr ( Y ≥ s / C , T ) = H [α_S_ + β_1_ * f_1_ ( C ) + β_2_ * f_2_ ( T )] Model 1 (D-9)

The Unrestricted Cumulative Model is described by the following equation:

Pr ( Y ≥ s / C , T ) = H [α_S_ + β_1 s_ * f_1_ ( C ) + β_2 s_ * f_2_ ( T )] Model 2 (D-10)

CatReg refers to any model of the form of Model 1 as a cumulative odds model because the model is expressed in terms of the cumulative probabilities, or odds, for Y ≥ s.

Note that Model 1 is a special case of Model 2 wherein parameters β1s and β2s do not depend on s (which denotes severity level). That is, Model 1 is a simplification of Model 2 in which only the intercept term can vary across severity levels, not the coefficients of dose or time (a restriction called parallelism, meaning the fitted slopes for severity levels will be parallel to one another).

In other words, the cumulative odds model (Model 1) states that:

- the probability that a severity level s or higher will occur at a given dose or concentration (C) and time (T) is given by the exposure-response curve (logistic, normal, or Gumbel, determined by the choice of link function), and
- the intercept parameters may differ by severity level (i.e., a different intercept for each severity level), but the coefficients for C and T do not differ by severity.

A primary use of fitting Model 2 is to test whether the simpler Model 1 is adequate. Model 2 has the undesirable feature that the regression lines for different severity levels are not parallel and may cross. Often the crossing is well outside the range of values of interest, so the model can be used to make empirical risk estimates. The user has the option to add an additional parameter, γ, which represents a hypothetical background concentration or dose, in some circumstances.

###### Understanding the Model Equations

The left-hand side of the Model 1 and Model 2 equations above is read as follows: the probability that a response of severity level s or greater occurs, given that concentration or dose is C and time is T (time refers to exposure duration). No expression for s = 0 is included because this is the minimal category, and Y is always greater than or equal to 0 (i.e., Pr(Y ≥ 0|C,T) = 1).

The right-hand side is described as follows:

- H is a probability function taking values between 0 and 1, for which the user has three choices: logistic, normal, and Gumbel.
- The parameter α_s_ is the intercept for severity level s, s = 2,…,S (to be called the intercept or severity parameters). The severity parameters are ordered as α_1_∃α_2_∃…∃α_s_. This constraint is a consequence of the requirement that the probability of exceeding a lower score is larger than the probability of exceeding a higher score for any fixed levels of C and T.
- In Model 1, the parameter β_1_ determines the dependence of the response on concentration or dose (I), whereas β_2_ determines the dependence on time (T). In Model 2, the parameters are also indexed by s because they may change values with severity level s.
- Current choices for ƒ_1_ and ƒ_2_ are “untransformed” and “base-10 logarithm.” Other transformations of C and T may be obtained by transforming the input data.

Parameters are α_s_, β_1s_ (to be called the coefficient of concentration or dose), β_2s_ (to be called the coefficient of time or duration), for severity levels s running from 1 to S. All parameters may be stratified on variables, as discussed in the CatReg User Guide (U.S. EPA, 2017)

###### CatReg Results

As described in Section 8.0 and 8.1 of the CatReg User Guide, hypothesis tests built into CatReg are designed to support the user with respect to model choice, parameter stratification and stratification/dataset configuration (e.g., whether intercept, dose and time parameter coefficients should be estimated separately by endpoint and/or sex). With respect to model choice, CatReg Model 2 results for the data shown in Table D-5 indicate that the simpler cumulative odds model (Model 1) is adequate for evaluating the (Kulle, 1993) eye and nasal/throat irritation datasets. Table D-6 shows the results of the CatReg hypothesis testing for a categorical regression analysis of the two irritation datasets, as well as a dataset combining the two endpoints, when intercept and slope parameters are stratified (estimated separately) by sex. The male nose/throat irritation data could not be analyzed separately because the estimated dose-response slope was negative. For both the eye irritation and combination datasets, the hypothesis test results suggest that the males and female data can be combined for the purpose of deriving the intercept and slope parameters (p > 0.05).

Table D-6 CatReg hypothesis test results for irritation datasets when intercept and slope parameters are stratified by sex

Dataset | Parameter | p-value | Conclusion
Eye Irritation | Intercept | 0.91 | Combine Intercept Data for Male and Female
Eye Irritation | Slope | 0.99 | Combine Slope Data for Male and Female
Nose/Throat Irritation | Intercept^*^ | -- | --
Nose/Throat Irritation | Slope^*^ | -- | --
| Intercept | 0.88 | Combine Intercept Data for Male and Female
Combined (Eye & Nose/Throat Irritation) | Slope | 0.61 | Combine Slope Data for Male and Female

* Could not model male nose/throat irritation separately due to negative slope.

The CatReg hypothesis test results for intercept and slope parameters stratified by eye and nose/throat irritation shown in Table D-7 suggest that, if male and female data are combined, the intercept parameter estimates for eye irritation and nose/throat irritation are similar but the slope parameters are not similar (p < 0.5), suggesting that the irritation data can be combined for the estimation of the intercept parameter but that separate slope parameters should be derived.

Table D-7 CatReg hypothesis test results for irritation datasets when intercept and slope parameters are stratified by endpoint, eye and nose/throat irritation

Dataset | Parameter | p-value | Conclusion
Male & Female | Intercept | 0.188 | Combine Intercept Data for Eye and Nose/Throat
Male & Female | Slope | 0.0022 | Stratify Slope Data by Eye and Nose/Throat
Male | Intercept^*^ | -- | --
Male | Slope^*^ | -- | --
Female | Intercept | 0.30 | Combine Intercept Data for Eye and Nose/Throat
Female | Slope | 0.11 | Combine Slope Data for Eye and Nose/Throat

* Could not model male nose/throat irritation separately due to negative slope

Table D-8 shows the CatReg modeling results for the combined male and female data using the combined eye and nose/throat irritation data (stratifying slope by endpoint) and separate endpoints results (female only is shown for nose/throat irritation given the negative slope in males). This table shows both the 95^th^ and 99^th^ percentile lower bound, as discussed above. The selected modeling results, based on the lowest AIC, are highlighted, with the selected POD of 0.36 ppm bolded. Also italicized are PODs representing the best-fitting 99^th^ percentile results from the other CatReg modeling outputs.

Table D-8 Summary of CatReg modeling results for sensory irritation

Endpoint and Dataset | Model^a^ | Severity^b^ | ERC10^c^, ppm | 95th Percentile LERC10, ppm | 99th Percentile LERC10, ppm | AIC^d^ | P-value
Eye irritation (male & female) | Logit | mild | 0.74 | 0.50 | 0.41 | 99.52 | <0.001
Eye irritation (male & female) | Logit | moderate | 1.71 | 1.33 | 1.17 | 99.52 | <0.001
Eye irritation (male & female) | Probit | mild | 0.67 | 0.46 | 0.38 | 99.28 | <0.001
Eye irritation (male & female) | Probit | moderate | 1.64 | 1.27 | 1.12 | 99.28 | <0.001
Eye irritation (male & female) | CLogLog | mild | 0.80 | 0.57 | 0.47 | 97.69 | <0.001
Eye irritation (male & female) | CLogLog | moderate | 1.71 | 1.32 | 1.16 | 97.69 | <0.001
Eye irritation data (male & female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Logit | mild | 0.62 | 0.46 | 0.39 | 177.73 | 0.0013
Eye irritation data (male & female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Logit | moderate | 1.81 | 1.42 | 1.26 | 177.73 | 0.0013
Eye irritation data (male & female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Probit | mild | 0.56 | 0.42 | 0.36 | 176.19 | 0.0010
Eye irritation data (male & female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Probit | moderate | 1.70 | 1.33 | 1.18 | 176.19 | 0.0010
Eye irritation data (male & female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | CLogLog | mild | 0.69 | 0.53 | 0.46 | 177.48 | 0.0012
Eye irritation data (male & female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | CLogLog | moderate | 1.85 | 1.45 | 1.29 | 177.48 | 0.0012
Nose/throat irritation data (female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Logit | mild | 1.44 | 0.84 | 0.59 | 177.73 | 0.0013
Nose/throat irritation data (female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Logit | moderate | 4.21 | 2.07 | 1.19 | 177.73 | 0.0013
Nose/throat irritation data (female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Probit | mild | 1.41 | 0.75 | 0.48 | 176.19 | 0.0010
Nose/throat irritation data (female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | Probit | moderate | 4.30 | 1.96 | 0.99 | 176.19 | 0.0010
Nose/throat irritation data (female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | CLogLog | mild | 1.48 | 0.90 | 0.66 | 177.48 | 0.0012
Nose/throat irritation data (female) to estimate slope and combined eye (male & female) and nose/throat irritation (female) data to estimate intercept | CLogLog | moderate | 3.98 | 2.09 | 1.30 | 177.48 | 0.0012
Nose/Throat Irritation (female) | Logit^e^ | mild | 0.76 | 0.42 | 0.28 | 41.42 | 0.0602
Nose/Throat Irritation (female) | Logit^e^ | moderate | -- | -- | -- | 41.42 | 0.0602
Nose/Throat Irritation (female) | Probit^e^ | mild | 0.72 | 0.38 | 0.24 | 41.61 | 0.0656
Nose/Throat Irritation (female) | Probit^e^ | moderate | -- | -- | -- | 41.61 | 0.0656
Nose/Throat Irritation (female) | CLogLog^e^ | mild | 0.81 | 0.49 | 0.36 | 41.26 | 0.0561
Nose/Throat Irritation (female) | CLogLog^e^ | moderate | -- | -- | -- | 41.26 | 0.0561

a All of the Link function models use Linear scale for dose and time.

b CatReg was used to estimate the probability of a 10% increase (the BMR) in any symptom incidence of this severity or greater.

c ERC and LERC are CatReg equivalents of the BMDS BMC and BMCL.

d The AIC values for the two different methods of combining the irritation datasets are identical because the same model was used (i.e., the model stratified dose on endpoint and gave results for both).

e The p-value of the model fit is > 0.05. This is generally considered not significant, indicating that the current model fit is not acceptable. These cells are shown in gray as they were not considered for use in derivation or comparison.

###### BMDS Results

BMDS^28^ was used to provide a comparison to the CatReg results. For the purposes of doing so, the data were pooled to provide a dichotomized comparison. Specifically, any incidence of symptoms with severity greater than mild were pooled into a single group for modeling purposes against the control (“none”) group. Table D-9 below shows the endpoints and data that were modeled. As with other modeling of these endpoints, a BMR of 10% extra risk was used, and results are presented for combined sexes for eye irritation and females alone for nose/throat irritation (both sexes were modeled individually for both endpoints with similar results, data not shown). Results were modeled and are shown with both the 95^th^ and 99^th^ percentile lower bound (Table D-10).

Table D-9 Incidence and severity of sensory irritation symptoms in humans after controlled formaldehyde exposure

Sensory irritation endpoint | Formaldehyde (ppm) | Symptom (any^a^) prevalence
Sensory irritation endpoint | Formaldehyde (ppm) | Males | | Females | | Males & Females
Sensory irritation endpoint | Formaldehyde (ppm) | None | Symptoms | None | Symptoms | None | Symptoms
Eye Irritation | 0 | 9/10 | 1/10 | 9/9 | 0/9 | 18/19 | 1/19
Eye Irritation | 0.5 | 4/4 | 0/4 | 6/6 | 0/6 | 10/10 | 0/10
Eye Irritation | 1 | 8/10 | 2/10 | 6/9 | 3/9 | 14/19 | 5/19
Eye Irritation | 2 | 5/10 | 5/10 | 4/9 | 5/9 | 9/19 | 10/19
Eye Irritation | 3 | 0/6 | 6/6 | 0/3 | 3/3 | 0/9 | 9/9
Nose/Throat Irritation | 0 | 9/10 | 1/10 | 7/9 | 2/9 | 16/19 | 3/19
Nose/Throat Irritation | 0.5 | 4/4 | 0/4 | 5/6 | 1/6 | 9/10 | 1/10
Nose/Throat Irritation | 1 | 9/10 | 1/10 | 9/9 | 0/9 | 18/19 | 1/19
Nose/Throat Irritation | 2 | 8/10 | 2/10 | 4/9 | 5/9 | 12/19 | 7/19
Nose/Throat Irritation | 3 | 6/6 | 0/6 | 1/3 | 2/3 | 7/9 | 2/9

a Any person with a symptom of severity rated ‘mild’ or greater was combined into a single ‘symptoms’ count.

Table D-10 BMD modeling summary for eye irritation in males and females

Model | BMC (ppm) | BMCL (95%) | BMCL (99%) | P-value | AIC | Notes
Hill | 0.852 | 0.510 | 0.362 | 0.147 | 67.596 | Viable
Gamma | 0.853 | 0.497 | 0.333 | 0.182 | 66.839 | Viable
LogLogistic | 0.852 | 0.510 | 0.362 | 0.147 | 67.596 | Viable
Multistage 1° | 0.270 | 0.191 | 0.167 | 0.063 | 71.876 | Questionable P-value^a^
Multistage 2° | 0.676 | 0.395 | 0.273 | 0.373 | 65.09 | Viable
Multistage 3° | 0.863 | 0.369 | 0.268 | 0.226 | 66.134 | Viable
Multistage 4° | 0.825 | 0.330 | 0.254 | 0.104 | 67.783 | Viable
Weibull | 0.886 | 0.501 | 0.348 | 0.211 | 66.225 | Viable
Logistic | 0.760 | 0.546 | 0.476 | 0.364 | 64.737 | Viable
LogProbit | 0.850 | 0.541 | 0.399 | 0.159 | 67.254 | Viable
Probit | 0.694 | 0.502 | 0.441 | 0.369 | 64.645 | Viable, Lowest AIC^b^
Quantal Linear | 0.270 | 0.191 | 0.167 | 0.063 | 71.876 | Questionable P-value^a^

a Goodness of fit p value was less than 0.1, so these results were non-preferred (gray). Other models were viable.

b BMDS recommended and EPA selected model (green highlighting), with the selected POD bolded.

Figure D-6 Selected BMDS model results (Probit model) for eye irritation (incidence) versus ppm formaldehyde exposure (ppm) in male and female adults (Kulle et al., 1993; 1987)

BMD = BMC.

Table D-11 BMD modeling summary of nose or throat irritation in females

Model | BMC (ppm) | BMCL (95%) | BMCL (99%) | P-value | AIC | Notes
Hill | 1.693 | 0.85 | 0.368 | 0.34 | 40.27 | Viable
Gamma | 1.369 | 0.601 | 0.292 | 0.208 | 41.493 | Viable
LogLogistic | 1.354 | 0.624 | 0.264 | 0.21 | 41.471 | Viable
Multistage 1° | 0.564 | 0.271 | 0.214 | 0.146 | 42.829 | Viable, Lowest BMCL^a^
Multistage 2° | 0.977 | 0.388 | 0.256 | 0.295 | 40.683 | Viable
Multistage 3° | 1.267 | 0.453 | 0.274 | 0.332 | 40.021 | Viable, Lowest AIC^b^
Multistage 4° | 1.267 | 0.448 | 0.274 | 0.332 | 40.021 | Viable, Lowest AIC
Weibull | 1.296 | 0.495 | 0.274 | 0.178 | 42.015 | Viable
Logistic | 0.758 | 0.493 | 0.414 | 0.213 | 41.417 | Viable
LogProbit | 1.37 | 0.697 | 0.236 | 0.231 | 41.222 | Viable
Probit^a^ | 0.715 | 0.467 | 0.396 | 0.205 | 41.608 | Viable
Quantal Linear | 0.564 | 0.271 | 0.214 | 0.146 | 42.829 | Viable

All models were viable.

a BMDS recommended model based on range of 95% BMCL values being > 3-fold (note: range of 99% BMCL values within 3-fold)

b Selected model (green highlighting) for the 99% BMCL values, with the selected POD bolded. An identical POD would be estimated using a more complex model with the same AIC.

Figure D-7 Selected BMDS model results (Multistage 3° model) for nose or throat irritation (incidence) versus ppm formaldehyde exposure (dose) in female adults (Kulle et al., 1993; 1987)

BMD =BMC.

##### Andersen and Molhave (1983, 1979)

Another experimental study exposed a group of 16 subjects to 0.3, 0.5, 1.0, and 2.0 mg/m^3^ formaldehyde for 5-hour periods with a 2-hour clean air exposure prior to each trial (Andersen, 1979; Andersen and Molhave, 1983). The order of exposure concentrations was randomized. The occurrence of irritation symptoms during the clean air exposure was not reported. The results of the different modeling approaches are summarized in Table D-12 and explained below.

Table D-12 Modeling summary for irritation symptoms in (Andersen, 1979; Andersen and Molhave, 1983)

Approach | Endpoint | Selected Model^a^ | BMC (mg/m^3^) | BMCL (95%) | BMCL (99%) | Notes
0% Background Prevalence | Prevalence of conjunctival redness and nose or throat dryness | LogLogistic | 0.26 | 0.16 | 0.11
3% Background Prevalence | Prevalence of conjunctival redness and nose or throat dryness | LogLogistic | 0.28 | 0.17 | 0.12 | Selected POD (bolded)
6% Background Prevalence | Prevalence of conjunctival redness and nose or throat dryness | LogLogistic | 0.30 | 0.18 | 0.13
9% Background Prevalence | Prevalence of conjunctival redness and nose or throat dryness | Hill | 0.45 | 0.25 | 0.18

a The selected model for each approach was the viable model with the lowest AIC (see details below).

The datasets modeled from this study (Andersen, 1979; Andersen and Molhave, 1983) are presented in Table D-13 below.

Table D-13 Sensory irritation symptom data from Andersen and Molhave (1983, 1979)

| Formaldehyde Level (mg/m^3^)
| 0 | 0.3 | 0.5 | 1.0 | 2.0
Prevalence of Discomfort^a^ (%) | Not reported^b^ | 3/16; (19%) | 5/16; (31%) | 15/16; (94%) | 15/16; (94%)

a Symptoms characterized as conjunctival irritation and dryness in the nose and throat.

b Clean-air exposure symptoms were not measured; Modeling assumed either 0% (incidence of 0/16 in the control group), 3% (incidence of 0.46/16 in the control group), 6%, or 9% background prevalence of symptoms.

BMD modeling was performed assuming a background prevalence of symptoms in controls of either 0% (see Table D-14 and Figure D-8 for results), 3% (see Table D-15 and Figure D-9 for results), 6% (see Table D-16 and Figure D-10 for results), or 9% (see Table D-17 and Figure D-11 for results).

Table D-14 BMD modeling summary of conjunctival irritation and dryness in the nose and throat dryness in males and females; 0 % background prevalence

Model | BMC (mg/m^3^) | BMCL (95%) (mg/m^3^) | BMDL (99%) (mg/m^3^) | P-value | AIC | Notes
Hill | 0.281 | 0.167 | 0.119 | 0.295 | 58.823 | Viable
Gamma | 0.208 | 0.091 | 0.062 | 0.195 | 58.846 | Viable, Large ratio^a^
LogLogistic | 0.257 | 0.157 | 0.112 | 0.401 | 57.33 | Viable, Lowest AIC^b^
Multistage 1° | 0.08 | 0.06 | 0.053 | 0.152 | 60.262 | Viable, Large ratio^a^
Multistage 2° | 0.138 | 0.068 | 0.057 | 0.114 | 60.321 | Viable, Large ratio^a^
Multistage 3° | 0.138 | 0.068 | 0.057 | 0.114 | 60.321 | Viable, Large ratio^a^
Multistage 4° | 0.138 | 0.068 | 0.057 | 0.114 | 60.321 | Viable, Large ratio^a^
Weibull | 0.169 | 0.077 | 0.06 | 0.17 | 59.527 | Viable, Large ratio^a^
Logistic | 0.256 | 0.182 | 0.158 | <0.001 | 62.408 | Questionable P-value^c^
LogProbit | 0.249 | 0.153 | 0.11 | 0.32 | 57.965 | Viable
Probit^a^ | 0.239 | 0.175 | 0.155 | <0.001 | 65.167 | Questionable P-value^c^
Quantal Linear | 0.08 | 0.06 | 0.053 | 0.152 | 60.262 | Viable, Large ratio^a^

a Lowest dose/BMCL and/or lowest dose/BMC ratio greater than 3, but results recommended as viable (no shading)

b BMDS recommended model and Selected model (green highlighting), with the selected POD bolded.

c Goodness of fit p value was less than 0.1, so these results were non-preferred (gray).

Figure D-8 Selected BMDS model results (LogLogistic model) for conjunctival irritation and dryness in the nose and throat dryness (incidence) versus mg/m^3^ formaldehyde exposure (dose) in male and female adults assuming a 0% background prevalence (Andersen and Molhave, 1983, 1979)

BMD = BMC.

Table D-15 BMD modeling summary of conjunctival irritation and dryness in the nose and throat in males and females; 3% background prevalence

Model | BMC (mg/m^3^) | BMCL (95%) (mg/m^3^) | BMDL (99%) (mg/m^3^) | P-value | AIC | Notes
Hill | 0.372 | 0.188 | 0.134 | 0.155 | 64.613 | Viable
Gamma | 0.224 | 0.099 | 0.064 | 0.088 | 65.24 | Questionable P-value and ratio^a^
LogLogistic | 0.279 | 0.167 | 0.12 | 0.23 | 63.536 | Viable, Lowest AIC^b^
Multistage 1° | 0.082 | 0.06 | 0.054 | 0.069 | 66.961 | Questionable P-value and ratio^a^
Multistage 2° | 0.151 | 0.071 | 0.059 | 0.045 | 66.808 | Questionable P-value and ratioy^a^
Multistage 3° | 0.151 | 0.071 | 0.059 | 0.045 | 66.808 | Questionable P-value and ratio^a^
Multistage 4° | 0.151 | 0.071 | 0.059 | 0.045 | 66.808 | Questionable P-value and ratio^a^
Weibull | 0.179 | 0.082 | 0.061 | 0.074 | 66.01 | Questionable P-value and ratio^a^
Logistic | 0.244 | 0.174 | 0.152 | 0.002 | 65.032 | Questionable P-value^a^
LogProbit | 0.266 | 0.161 | 0.116 | 0.169 | 64.262 | Viable
Probit^a^ | 0.229 | 0.169 | 0.15 | 0.003 | 67.549 | Questionable P-value^c^
Quantal Linear | 0.082 | 0.06 | 0.054 | 0.069 | 66.961 | Questionable P-value and ratio^a^

a Goodness of fit p value was less than 0.1 and lowest dose/BMCL ratio and/or lowest dose/BMC ratio greater than 3, so these results were non-preferred (gray).

b BMDS recommended model and Selected model (green highlighting), with the selected POD bolded.

c Goodness of fit p value was less than 0.1, so these results were non-preferred (gray).

Figure D-9 Selected BMDS model results (LogLogistic model) for conjunctival irritation and dryness in the nose and throat dryness (incidence) versus mg/m^3^ formaldehyde exposure (dose) in male and female adults assuming a 3% background prevalence (Andersen and Molhave, 1983, 1979)

BMD = BMC.

Table D-16 BMD modeling summary of conjunctival irritation and dryness in the nose and throat in males and females; 6 % background prevalence

Model | BMC (mg/m^3^) | BMCL (95%) (mg/m^3^) | BMDL (99%) (mg/m^3^) | P-value | AIC | Notes
Hill | 0.43 | 0.223 | 0.157 | 0.284 | 66.712 | Viable
Gamma | 0.24 | 0.107 | 0.067 | 0.081 | 68.294 | Questionable P-value^a^
LogLogistic | 0.3 | 0.178 | 0.128 | 0.223 | 66.407 | Viable, Lowest AIC^b^
Multistage 1° | 0.083 | 0.061 | 0.054 | 0.058 | 70.321 | Questionable P-value and ratio^a^
Multistage 2° | 0.166 | 0.074 | 0.06 | 0.038 | 69.945 | Questionable P-value and ratio^a^
Multistage 3° | 0.166 | 0.074 | 0.06 | 0.038 | 69.945 | Questionable P-value and ratio^a^
Multistage 4° | 0.166 | 0.074 | 0.06 | 0.038 | 69.945 | Questionable P-value and ratio^a^
Weibull | 0.189 | 0.087 | 0.063 | 0.068 | 69.155 | Questionable P-value and ratio^a^
Logistic | 0.233 | 0.168 | 0.147 | 0.01 | 67.49 | Questionable P-value^a^
LogProbit | 0.284 | 0.17 | 0.124 | 0.162 | 67.217 | Viable
Probit^a^ | 0.22 | 0.164 | 0.146 | 0.01 | 69.778 | Questionable P-value^c^
Quantal Linear | 0.083 | 0.061 | 0.054 | 0.058 | 70.321 | Questionable P-value and ratio^a^

a Goodness of fit p value was less than 0.1 and lowest dose/BMCL ratio and/or lowest dose/BMC ratio greater than 3, so these results were non-preferred (gray).

b BMDS recommended model and Selected model (green highlighting), with the selected POD bolded.

c Goodness of fit p value was less than 0.1, so these results were non-preferred (gray).

Figure D-10 Selected BMDS model results (LogLogistic model) for conjunctival irritation and dryness in the nose and throat dryness (incidence) versus mg/m^3^ formaldehyde exposure (dose) in male and female adults assuming a 6% background prevalence (Andersen and Molhave, 1983, 1979)

BMD = BMC.

Table D-17 BMD modeling summary of conjunctival irritation and dryness in the nose and throat in males and females; 9% background prevalence

Model | BMC (mg/m^3^) | BMCL (95%) (mg/m^3^) | BMDL (99%) (mg/m^3^) | P-value | AIC | Notes
Hill | 0.446 | 0.252 | 0.177 | 0.435 | 68.576 | Viable, Lowest AIC^b^
Gamma | 0.256 | 0.115 | 0.069 | 0.073 | 70.838 | Questionable P-value^a^
LogLogistic | 0.32 | 0.188 | 0.137 | 0.209 | 68.787 | Viable
Multistage 1° | 0.085 | 0.062 | 0.055 | 0.049 | 73.168 | Questionable P-value and ratio^a^
Multistage 2° | 0.183 | 0.077 | 0.062 | 0.032 | 72.56 | Questionable P-value and ratio^a^
Multistage 3° | 0.183 | 0.077 | 0.062 | 0.032 | 72.56 | Questionable P-value and ratio^a^
Multistage 4° | 0.183 | 0.077 | 0.062 | 0.032 | 72.56 | Questionable P-value and ratio^a^
Weibull | 0.2 | 0.091 | 0.065 | 0.061 | 71.792 | Questionable P-value and ratio^a^
Logistic | 0.224 | 0.162 | 0.142 | 0.025 | 69.796 | Questionable P-value^a^
LogProbit | 0.301 | 0.179 | 0.131 | 0.153 | 69.666 | Viable
Probit^a^ | 0.213 | 0.16 | 0.142 | 0.02 | 71.87 | Questionable P-value^c^
Quantal Linear | 0.085 | 0.062 | 0.055 | 0.049 | 73.168 | Questionable P-value and ratio^a^

a Goodness of fit p value was less than 0.1 and lowest dose/BMCL ratio and/or lowest dose/BMC ratio greater than 3, so these results were non-preferred (gray).

b BMDS recommended model and Selected model (green highlighting), with the selected POD bolded.

c Goodness of fit p value was less than 0.1, so these results were non-preferred (gray).

Figure D-11 Selected BMDS model results (Hill model) for conjunctival irritation and dryness in the nose and throat dryness (incidence) versus mg/m^3^ formaldehyde exposure (dose) in male and female adults assuming a 9% background prevalence (Andersen and Molhave, 1983, 1979)

BMD = BMC.

### D.1.2 Pulmonary Function

#### Estimates from Observational Epidemiology Studies

A cross-sectional study of residential formaldehyde exposure in a large population-based sample observed a linear relationship between increased formaldehyde exposure and decreased peak expiratory flow rate (PEFR) among children exposed to average concentrations of 0.032 mg/m^3^ (26 ppb) (Krzyzanowski et al., 1990). This study of effects in a residential population used a thorough exposure assessment protocol and repeated measurements of PEFR, thus, enhancing the ability to detect an association at the lower concentrations found in the homes. Declines in peak expiratory flow rate (PEFR) were associated with increases in 2-week average indoor residential formaldehyde concentrations, with greater declines observed in children (5–15 years of age, n = 208 in analytical data set) compared to adults (Krzyzanowski et al., 1990). Mean formaldehyde levels were 26 ppb (0.032 mg/m^3^), and more than 84% of the homes had concentrations 40 ppb (0.049 mg/m^3^) and lower.

EPA calculated the concentration at which a 10% decrement in pulmonary function would be expected. In this derivation, 10% decrement in a continuous response is considered to be the benchmark response (BMR). A BMC_10%_ and BMCL_10%_ were determined from the regression coefficient from a random effects model of PEFR among children reported by the study authors. Statistical models which adjusted for important covariates (including smoking status, SES, NO_2_ levels, episodes of acute respiratory illness, and the time of day) did not identify any potential confounders and those covariates were not included in the final model.

y = 349.6 − 1.28 * ( h o u s e h o l d f o r m a l d e h y d e ) − 6.1 * ( m o r n i n g ) + 0.09 * ( b e d r o o m f o r m a l d e h y d e ) * ( m o r n i n g ) + 0.0031 * ( b e d r o o m f o r m a l d e h y d e )^2^ * ( m o r n i n g ) + 4.59 * ( m o r n i n g ) * ( a s t h m a ) − 1.45 * ( b e d r o o m f o r m a l d e h y d e ) * ( m o r n i n g ) * ( a s t h m a ) + 0.031 ( b e d r o o m f o r m a l d e h y d e ) * ( m o r n i n g ) * ( a s t h m a ) (D-11)

where y = PEFR (L/min); household formaldehyde = 2-week household mean concentration; morning = time of PEFR measurement (0,1); 2-week bedroom mean concentration; current asthma = doctor’s diagnosis and current status (0,1).

For the purpose of deriving a point of departure for indoor formaldehyde, the primary estimate of the point of departure was computed for household formaldehyde with morning = 0 and asthma =0. The regression coefficient (β) for household formaldehyde was −1.28 ± 0.46 L/minute-ppb and the 95% one-sided upper bound on the regression coefficient was −2.04 L/minute-ppb;

β − ( c r i t i c a l v a l u e f o r o n e − t a i l e d α o f 0.05 * s . e . o f β ) = − 1.28 − ( 1.645 * 0.46 ) = − 2.04 (D-12)

Based on the background PEFR of 349.6 L/minute, a 10% decrement is 35 L. Dividing 35 L by the regression coefficient for household formaldehyde of −1.28 L/minute-ppb (i.e., −1.28 L/(minute*ppb)), the change in formaldehyde concentration resulting in a 10% decrement in PEFR is 27 ppb which is equivalent to 0.033 mg/m^3^. The BMCL resulting in a 10% decrease from a background of 349.6 L/minute is 17 ppb (35 L/minute divided by −2.04 L/minute-ppb), which is equivalent to 0.021 mg/m^3^.

In order to estimate how much more sensitive asthmatic children were to formaldehyde, household and bedroom formaldehyde concentrations were assumed to be the same and morning = 1 and asthma = 1. Solving the final regression model for these realizations of household formaldehyde, bedroom formaldehyde, morning, and asthma yield the following:

− 35 L / min = − 1.28 * ( h o u s e h o l d f o r m a l d e h y d e ) − 6.1 * ( 1 ) + 0.09 * ( h o u s e h o l d f o r m a l d e h y d e ) * ( 1 ) + 0.0031 * ( h o u s e h o l d f o r m a l d e h y d e )^2^ * ( 1 ) + 4.59 * ( 1 ) * ( 1 ) − 1.45 * ( h o u s e h o l d f o r m a l d e h y d e ) * ( 1 ) * ( 1 ) + 0.031 ( h o u s e h o l d f o r m a l d e h y d e )^2^ * ( 1 ) * ( 1 ) (D-13)

which simplifies to:

− 35 (L)/(min) = 0.0341 * ( h o u s e h o l d f o r m a l d e h y d e )^2^ − 2.64 * ( h o u s e h o l d f o r m a l d e h y d e ) − 1.51 (D-14)

Solving for household formaldehyde yields a BMC_10%_ (asthmatics) resulting in a 10% decrease from a background PEFR of 349.6 L/minute of 16 ppb given that asthmatic children were more sensitive to the respiratory effects of formaldehyde exposure than were children in general who had BMC_10%_ of 27 ppb.

### D.1.3 Asthma Exacerbation

#### Estimates from Observational Epidemiology Studies

Venn et al. (2003) studied how indoor formaldehyde exposures affected the proportion of childhood asthma cases who reported symptoms of asthma attacks (asthma exacerbation). During an asthma attack, the muscles of the airways constrict thereby limiting air flow and the cells in the airway produce mucus which further restricts the passage of air. Symptoms included any of the following: wheezing, chest tightness, breathlessness, or cough (Venn et al., 2003). According to the Centers for Disease Control and Prevention (Moorman et al., 2012), more than 50% of children with asthma experienced at least one asthma attack in the previous 12 months yielding an annual rate of asthma attacks in the general population of children of more than 5%. Approximately 10% of children with asthma suffer an asthma attack resulting in a visit to the emergency room each year. The annual mortality rate from asthma among children is 2–3 per million (Moorman et al., 2012).

Venn et al. (2003) (see Table D-18) divided the children’s bedroom formaldehyde exposures into quartiles and reported a statistically significant exposure-response trend of increasing risk of symptoms of an asthma attack with increasing quartiles of formaldehyde concentrations (p = 0.03) and then fit a regression model to estimate the “per quartile” increase in risk. Venn et al. (2003) identified similar exposure-response functions for night-time and daytime symptoms of an asthma attack (asthma exacerbation) in children with asthma^29^: for night-time symptoms, the odds ratio (OR) per exposure quartile increase in formaldehyde concentration was 1.45 (95% CI: 1.06–1.98); for daytime symptoms, the OR per exposure quartile was 1.40 (95% CI: 1.00–1.94)^30^. Results were adjusted for age, sex, and socioeconomic status. Dampness was also reported to be a risk factor for symptoms of an asthma attack; however, further adjustment of the formaldehyde results for dampness made little difference (Venn et al., 2003). No effect of other volatile organic compounds or nitrogen dioxide on the risk of asthma attacks was found.

As the formaldehyde measures were taken in the children’s bedrooms, the RfC derivation is based on the exposure-response function for night-time symptoms of an asthma attack. The following table summarizes the results from Venn et al. (2003) specific to the exposure-response relationship for night-time symptoms of asthma attacks in children with asthma. Note that, by definition, the OR reported for each exposure level is relative to the odds of being a case in the reference category, which is the lowest quartile of exposure. In Venn et al. (2003), the reference category is defined as exposures within the range 0–16 μg/m^3^. The median concentration within this range was 12.24 μg/m^3^ (Venn, 2012). In order to estimate the OR per unit increase in formaldehyde concentration from the reported effect per unit increase in quartile of formaldehyde exposure, the difference in each quartile’s median formaldehyde concentration was computed by subtracting 12.24 μg/m^3^ from each quartile median.

Table D-18 Modeled effect estimates for night-time symptoms of an asthma attack; data from (Venn et al., 2003)

Exposure quartile^a^ (μg/m^3^) | Quartile median^b^ (μg/m^3^) | Quartile median > reference quartile (μg/m^3^) | OR by quartile^a^ | Lower bound OR by quartile | Upper bound OR by quartile | Modeled OR^c^ | Lower bound modeled OR^c^ | Upper bound bodeled OR^c^
0–16 | 12.24 | 0 | 1 | | | 1
16.1–22 | 19.23 | 6.99 | 1.4 | 0.54 | 3.62 | 1.45 | 1.06 | 1.98
22.1–32 | 26.55 | 14.31 | 1.61 | 0.62 | 4.19 | 2.10 | 1.12 | 3.92
32+ | 41.02 | 28.78 | 3.33 | 1.23 | 9.01 | 3.05 | 1.19 | 7.73

a (Venn et al., 2003);

b (Venn, 2012);

c (Venn et al., 2003) OR per increasing quartile = 1.45 (95% CI: 1.06–1.98).

EPA considered multiple methodologies for identifying a point of departure for this health endpoint. If the information provided by Venn et al. (2003) had been limited to just the quartile-specific results, then the one method might have used the results from Table D-18 of Venn et al. (2003) which show the first statistically significant effect occurring in the highest exposure group with a quartile mean of 41.02 μg/m^3^ which could represent the LOAEL and thus the corresponding NOAEL could be the quartile mean of the third exposure group at 26.55 μg/m^3^. However, because Venn et al. (2003) also reported a statistically significant exposure-response function (p-trend = 0.02) with OR=1.45 per exposure quartile (95% CI: 1.06–1.98), it is not reasonable to assume there is no effect at the median of the third quartile because the reported OR for this quartile was 1.61 (95% CI: 0.62–4.19) and the reported exposure-response function corresponds to a modeled OR=2.10 (95% CI: 1.12–3.92). Likewise, for the second quartile with a quartile-specific result of OR=1.4 (95% CI: 0.54–3.62), rather than evidence of “no effect,” the reported exposure-response function indicates a modeled OR = 1.45 (95% CI: 1.06–1.98), which is consistent with the second quartile-specific results of OR = 1.4 but has narrower confidence intervals due to the use of data from all the quartiles rather than just a comparison of the second quartile to the first.

The reported exposure-response function from Venn et al. (2003) appears to be a more precise estimate of the exposure-response relationship for night-time symptoms of poor asthma control in children with asthma. In order to estimate a point of departure, the units of ‘per quartile’ need to be defined in terms of “per μg/m^3^.” As the magnitude of the increase in exposure from the median of the first quartile to the median of the second quartile is 6.99 μg/m^3^, an estimate of the effect of exposure per μg/m^3^ can be obtained by scaling the ln(OR) and its standard error by the difference in quartile medians. The OR = 1.45 per quartile (95% CI: 1.06–1.98) is first converted to the natural log scale as ln(OR) = 0.37156 per quartile (95%: 0.05827–0.68310), and then each term is multiplied by unity as expressed by [(1 quartile)/(6.99 μg/m^3^)] to yield an effect of ln(OR) = 0.053156 (95% CI: 0.008336–0.09773), which when exponentiated back to the OR scale is equivalent to an OR = 1.05 per μg/m^3^ (95% CI: 1.01–1.10). This equivalent exposure-response function in terms of “per μg/m^3^” retains the same p-trend value of 0.02 because the scaling cancels out.

According to Table B-8 in Venn et al. (2003), the prevalence of night-time asthma symptoms among the cases in the reference group is 0.41. Because the symptoms of an asthma attack among children with asthma is considered to be a frank effect (an overt of clinically apparent effect), a BMR of 5% was used to derive the POD for the derivation of the RfC (U.S. EPA, 2012). Using a BMR=5% extra risk for symptoms of an asthma attack, the prevalence of symptoms among the exposed at 5% extra risk compared to the prevalence of symptoms at zero exposure is:

Extra Risk = 0.05 = [P_Exposed_ − P_Unexposed_] ÷ [1 − P_Unexposed_] and P_Unexposed_ = 0.41 , then P_Exposed_ = 0.4395. (D-15)

Find OR = [P_Exposed_ / (1 − P_Exposed_)] / [P_Unexposed_ / (1 − P_Unexposed_)] = [ 0.4395 / ( 1 − 0.4395 ) ] / [ 0.41 / ( 1 − 0.41 ) ] = 1.13 (D-16)

For the derivation of the point of departure, here the benchmark concentration or BMC, note that the exposure-response function is defined relative to the reference group (those exposed to the first quartile of formaldehyde exposures) which experienced a median formaldehyde concentration of 12.24 μg/m^3^ (Venn, 2012), personal communication personal communication. So, in deriving the BMC, the first step is to estimate the magnitude of the concentration above the reference concentration of 12.24 μg/m^3^, which corresponds to a 5% extra risk. For clarity, that value will be called the “interim BMC_05_.” The second step is to add that interim BMC_5_ to the median formaldehyde concentration in the reference group. While it is possible that there are adverse effects of formaldehyde below the median formaldehyde concentration in the reference group, it should be understood that the methodology used in this derivation restricts the BMC to be greater than the median formaldehyde concentration in the reference group. The alternative would be to extrapolate the exposure-response function down from 12.24 μg/m^3^ to either the background ambient formaldehyde concentration, or down to a concentration of zero.

To derive the interim BMC using the linear concentration-response function, solve for:

- OR corresponding to a 5% extra risk = 1.13 = (1.05 per μg/m^3^)*(Interim BMC_5_)
- Interim BMC_5_ = 1.08 μg/m^3^

To derive the interim BMCL using the linear concentration-response function, the one-sided 95% upper bound is needed (rather than the upper bound of the two-sided 95% CI around the OR). Using the one-sided 95% upper bound, which is 1.09 (calculation below)^31^, solve for:

- OR corresponding to a 5% extra risk = 1.13 = (1.09 per μg/m^3^)*(Interim BMCL_5_)
- Interim BMCL_5_ = 1.04 μg/m^3^

Adding back the median formaldehyde concentration in the reference category (12.24 μg/m^3^), the BMCL_5_ value is 13.28 μg/m^3^ and this value is selected as the point of departure for the cRfC.

### D.1.4 Respiratory Tract Pathology

#### Estimates from Experimental Animal Studies

This appendix provides support to the decisions and details of modeling the respiratory pathology data in rats and mice in Section 5.1.2 for deriving candidate RfCs based on these endpoints. These involve the following endpoints and studies: squamous metaplasia in F344 rats (Kerns et al., 1983), basal hyperplasia in Wistar rats (Woutersen et al., 1989), and squamous metaplasia in Wistar rats (Woutersen et al., 1989).

Figure D-12 Midsaggital section of rat nose showing section levels from (Kerns et al., 1983) (nostril is to the left)

Formaldehyde flux to the nasal lining was used in analyzing the dose-response data from Kerns et al. (1983) at the Level 1 cross section (Figure D-12) of the F344 rat nose, which is located in the front portion of the rat nose behind the nasal vestibule (Young, 1981). The 18-month data was chosen for modeling; while it would have been preferable to use the 24-month dose-response, these data could not be modeled because of a very steeply rising dose-response curve resulting in unbounded confidence limits (see Table D-19).

Table D-19 Incidence of squamous metaplasia in nasal cavity of F344 rats

Level I
Duration | 0 mg/m^3^ | 2.5 mg/m^3^ | 6.9 mg/m^3^ | 17.6 mg/m^3^
6 months | NA | 4/20 | 10/20 | NA
12 months | NA | 7/20 | 11/20 | NA
18 months | 0/40 | 24/40 | 35/40 | 38/39
24 months | 1/101 | 91/94 | 81/82 | 27/27
27 months | 3/19 | 4/20 | 8/19 | 5/5
30 months | 1/10 | 2/5 | 1/8 | NR

Kimbell et al. (2001b) modeled formaldehyde flux to the nasal lining in the F344 rat and human; their flux estimates are shown in Figure D-13 as a contour plot of flux per ppm of exposure (note: only the lateral view of the three-dimensional surface is presented). The plot in the top panel of the figure indicates that formaldehyde flux per ppm of exposure to the surface of the Level 1 section would correspond to the upper range (greater than approximately 1,750 pmol/mm^2^-h-ppm) of flux estimates per ppm exposure. (Kimbell et al., 2001b) divided their total flux (per ppm of exposure) range in the rat into 20 flux bins with the mean flux in bin 14 equal to 1,764 pmol/mm^2^-hour-ppm of exposure (see Table 1, (Kimbell et al., 2001b)). Therefore, we use flux estimates from flux bins 14-20 of their paper; the surface-area-weighted average flux per ppm of exposure in these flux intervals is 1,879.66 pmol/mm^2^-hour per ppm (i.e., 1,528.18 pmol/mm^2^-hour per mg/m^3^) of exposure. Therefore, average flux in the Level 1 region corresponding to the BMCL_10_ of 0.448 mg/m^3^ is estimated to be 1,528.18 × 0.448= 685 pmol/mm^2^-hour.

In order to extrapolate the above BMCL to the human, one is interested in knowing the human exposure concentration at which some region in the human nose (see Figure D-13) is exposed to a formaldehyde flux of 685 pmol/mm^2^-hour. This is estimated from Table 3 in (Kimbell et al., 2001b), which tabulates formaldehyde flux to the human nasal lining at various inspiratory rates. At any given exposure, the anterior regions of the nose are subject to the highest concentrations of formaldehyde; therefore, we averaged the data from flux bins 17–20 in their tabulation, which receive the highest levels of flux. The average flux per ppm of exposure concentration in bins 17–20 in the human is 1,741 pmol/mm^2^-hour per ppm of exposure. Thus, the exposure concentration at which these regions would receive a flux of 685 pmol/mm^2^-hr is 0.484 mg/m^3^. This is the human BMCL corresponding to 0.10 extra risk, which was selected because the observed squamous metaplasia was determined to be of minimal-to-mild adversity. As an aside, it is instructive to note that the values for the rat and human BMCLs are roughly the same, a result that one would expect if the principle of ppm-equivalence across species is applied.

As discussed in Section 3.2.4 of the Toxicological Review, squamous metaplasia occurred in several sagittal cross sections (Level 1–5, depicted in Figure D-13) of the F344 rat nose in the Kerns et al. (1983) study. However, accurate estimates of formaldehyde flux over the nasal lining other than Level 1 were not available to EPA, and flux estimates provided in Kimbell et al. (2001b) cannot be reliably used for the other cross-sections because of a lack of correspondence with the nasal regions in their paper. Therefore, only the squamous metaplasia data reported for Level 1 was carried forward in calculating a candidate RfC. Details of benchmark dose modeling for data on squamous metaplasia in F344 rat and squamous metaplasia and basal hyperplasia in Wistar rat are shown in Table D-20 and Figures D-14 to D-16.

Table D-20 Benchmark dose modeling of rat respiratory histopathological effects

Model^a^ | BMR | AIC | BMC | BMCL | P-value | Best model^b^ | Notes
Squamous metaplasia in F344 rat (Level 1)
Mstage k=2 | 0.10 | 97.779 | 0.351 | 0.281 | 0.253
Mstage k=1 | 0.10 | 97.779 | 0.351 | 0.281 | 0.253
Log-logistic | 0.10 | 97.322 | 0.492 | 0.119 | 0.981 | | BMC/BMCL > 3
Log-Probit^c^ | 0.10 | 95.619 | 0.576 | 0.448 | 0.947 | √ | Lowest AIC
Basal hyperplasia in Wistar rat (anterior, Levels 1 & 2)^d^
Dichotomous Hill | 0.10 | 65.975 | 1.634 | 0.487 | 0.309 | | Lowest BMCL, BMC/BMCL > 3
Mstage k=1^e^ | 0.10 | 63.846 | 1.676 | 1.108 | 0.620 | √ | Lowest AIC
Squamous metaplasia in Wistar rat (anterior, Levels 1 & 2)^d,f^
Probit | 0.10 | 70.725 | 1.291 | 0.939 | 0.406 | | Lowest AIC
Log-probit^c^ | 0.10 | 71.779 | 0.821 | 0.459 | 0.298 | √^f^ | Lowest residual^f^
Multistage k=1 | 0.10 | 71.722 | 0.395 | 0.267 | 0.226 | | Lowest BMCL

a Figures D-14 to D-16 show fits for all the models evaluated; only models that provided a reasonable fit are tabulated.

b Shown in bottom panels of Figures D-14 to D-16 along with the BMD/BMDL.

c Model was restricted to prevent the slope of the dose-response from becoming unbounded at zero dose.

d Exposure concentrations were 0, 0.123, 1.23 & 12.05 mg/m^3^; observed incidences were 0/26, 1/26, 2/28 & 14/26 for basal hyperplasia, and 3/26, 1/26, 6/28 & 25/26 for squamous metaplasia.

e This model gives identical AIC, BMD and BMDL values as the Gamma and Weibull models.

f This data set is noisy in the lower dose groups. The probit model has the lowest AIC but gives a scaled residual of 0.72 which is high compared to the value of 0.002 from the log-probit for the dose group near the BMD. The AIC for the log-probit model, while higher, is within a value of 2.0 from that of the probit, and better fits the trend. The multistage model results in a scaled residual of −0.90, an even higher absolute value.

Figure D-13 Lateral view of contour plot of formaldehyde flux to the rat (on the top) and human nasal lining (on the bottom) using CFD modeling (Kimbell et al., 2001b) (nostril is to the right)

The actual surface is three-dimensional. Flux at a site is linear with exposure concentration and is shown here in terms of per ppm; therefore, values shown here need to be multiplied by exposure concentration. Rectangular boxes on the rat mesh roughly estimate location of section Levels 1 & 2 in (Kerns et al., 1983) (corresponding to Figure D-12).

Figure D-14 All model fits (top panel) and best fitting log-probit model (bottom panel) for level 1 squamous metaplasia (F344 rat)

BMR is at 0.1 extra risk, BMDL is at 95% lower confidence bound.

Figure D-15 All model fits (top panel) and best fitting Multistage (k=1) model (bottom panel) for basal hyperplasia (Wistar rat)

BMR is at 0.1 extra risk, BMDL is at 95% lower confidence bound.

Figure D-16 All model fits (top panel) and best fitting log-probit model (bottom panel) for squamous metaplasia (Wistar rat)

BMR is at 0.1 extra risk, BMDL is at 95% lower confidence bound.

### D.1.5 Reproductive Toxicity in Males

#### Estimates from Experimental Animal Studies

Two medium confidence studies reporting effects on the male reproductive system in rats were considered for candidate reference value derivation (Ozen et al., 2002; Ozen et al., 2005) (see modeled study details in Table D-21). For each endpoint, the BMDL estimate (95% lower confidence limit on the BMD, as estimated by the profile-likelihood method) and AIC value were used to select a best-fit model from among the models exhibiting adequate fit. If the BMDL estimates were “sufficiently close,” that is, differed by at most 3-fold, the model selected was the one that yielded the lowest AIC value. If the BMDL estimates were not sufficiently close, the lowest BMDL was selected as the POD. One study (Ozen et al., 2005) included findings after both four and 13 weeks of formaldehyde exposure; however, only the 13-week data were advanced for POD derivation given the goal of developing a lifetime toxicity value.

Table D-21 Endpoints selected for dose-response modeling for reproductive and developmental toxicity in animals

Species (strain)/Sex Endpoint | Adjusted Formaldehyde Concentrations and Effect Data
Ozen et al. (2005), Table 1
Rat (Wistar)/adult males, 13-wk exposure | Concentration (mg/m^3^)^a^ | 0 | 6.15 | 12.3
Serum testosterone (ng/L) | No. of animals; Mean ± SD | 6; 406.5 ± 41.20 | 6; 244.0 ± 58.44 | 6; 141.3 ± 20.97
Ozen et al. (2002), Table 2
Rat (Wistar)/adult males, 13-wk exposure | Concentration (mg/m^3^) | 0 | 12.2 | 24.4
Testis weight as percent of body weight | No. of animals; Mean ± SD | 7; 0.91 ± 0.01 | 7; 0.84 ± 0.03 | 7; 0.82± 0.03

a Reported as 0, 5, and 10 ppm. Conversion: ppm*1.23.

##### Serum Testosterone in Male Rats

For the BMD modeling of serum testosterone in male Wistar rats exposed to formaldehyde by inhalation for 13 weeks (Ozen et al., 2005), model fit to the mean responses was good. Fit of the models for variance was marginal because the reported sample estimates of standard deviations (SD) did not change monotonically with concentrations (see Table D-22).

Table D-22 Summary of BMDS modeling for serum testosterone in male Wistar rats exposed to formaldehyde by inhalation for 13 weeks (Ozen et al., 2005); BMR = 1 SD change from the control mean

Model | BMC (mg/m^3^) | BMCL (95%) | BMCL_ADJ_^a^ | P-value | AIC | Notes
Exponential (M3) | 1.322 | 0.878 | 0.209 | - | 191.221 | Questionable^b^
Exponential (M5) | 1.34 | 0.797 | 0.190 | - | 193.221 | Questionable^b^
Hill | 3.53 | 0.713 | 0.170 | - | 193.221 | Questionable^b^
Polynomial 2° | 1.931 | 1.464 | 0.349 | 0.139 | 191.405 | Viable
Power | 1.935 | 1.465 | 0.349 | 0.140 | 191.402 | Viable, Lowest AIC^c^
Linear | 1.935 | 1.465 | 0.349 | 0.140 | 191.402 | Viable

a Conversion: (mg/m3)*(8 hrs/24 hrs)*(5 d/7 d).

b Zero degrees of freedom, saturated model, therefore goodness of fit cannot be calculated.

c BMDS recommended and EPA selected model (green highlighting), with the selected POD and PODADJ bolded.

Figure D-17 Plot of mean response (serum testosterone, serum testosterone,(Ozen et al., 2005)) by formaldehyde concentration (mg/m^3^), with the fitted curve for the Power model

BMR = 1 SD change from the control mean. Concentrations are in mg/m^3^.

##### Relative Testis Weight in Male Rats

As shown in Tables D-23 and D-24, BMDS models could not be fitted successfully to data for testis weight as a percentage of body weight (Ozen et al., 2002) at the 13-week exposure duration because they reduce to linear models that had large-scaled residuals (poor fit).

Table D-23 Summary of BMDS modeling for relative testis weight in male Wistar rats exposed to formaldehyde by inhalation for 13 weeks (Ozen et al., 2002); BMR = 10% RD

Model | BMC (mg/m^3^) | BMCL (95%) | BMCL_ADJ_^a^ | P-value | AIC | Notes
Exponential (M3) | 24.232 | 19.223 | 4.577 | 0.0363 | −87.915 | Questionable^c,d^
Exponential (M5) | 25.7 | 12.131 | 2.888 | - | −90.297 | Questionable^b,c^
Hill | 25.376 | 13.192 | 3.141 | - | −90.297 | Questionable^b,c^
Polynomial 2° | 24.397 | 19.582 | 4.523 | 0.0287 | −87.512 | Questionable^c,d^
Power | 24.445 | 19.584 | 4.662 | 0.0287 | −87.513 | Questionable^c,d^
Linear | 24.445 | 19.583 | 4.663 | 0.0287 | −87.513 | Questionable^c,d^

a Conversion: (mg/m^3^)*(8 hrs/24 hrs)*(5 d/7 d).

b Zero degrees of freedom, saturated model.

c Constant variance test failed (Test 2 p-value < 0.05); control stdev fit > 1.5.

d Goodness of fit p-value less than 0.1.

Table D-24 Summary of BMDS modeling for relative testis weight in male Wistar rats exposed to formaldehyde by inhalation for 13 weeks (Ozen et al., 2002); BMR = 1 SD change from the control mean

Model | BMC (mg/m^3^) | BMCL (95%) | BMCL_ADJ_^a^ | P-value | AIC | Notes
Exponential (M3) | 6.687 | 4.857 | 1.156 | 0.0363 | −87.915 | Questionable^c,d^
Exponential (M5) | 2.644 | 0.177 | 0.042 | - | −90.297 | Questionable^b,c^
Hill | 2.214 | 0 | - | - | −90.297 | Unusable, BMCL does not exist^b,c^
Polynomial 2° | 7.064 | 5.185 | 1.235 | 0.0287 | −87.512 | Questionable^c,d^
Power | 7.079 | 5.185 | 1.235 | 0.0287 | −87.513 | Questionable^c,d^
Linear | 7.079 | 5.184 | 1.234 | 0.0287 | −87.513 | Questionable^c,d^

a Conversion: (mg/m^3^)*(8 hrs/24 hrs)*(5 d/7 d).

b Zero degrees of freedom, saturated model.

c Constant variance test failed (Test 2 p-value < 0.05); control stdev fit > 1.5.

d Goodness of fit p-value less than 0.1.

An alternative approach to POD derivation is the NOAEL/LOAEL approach. EPA calculations indicate that if the data are normally distributed (unverified, but plausible for relative weights), the response at the first concentration represents a decrease of 7.7% below control (95% confidence interval 4.6% to 11%), and the response at the second concentration represents a decrease of 11% (95% confidence interval 7.9% to 14%). The response at the second concentration is closest to the target BMR for organ weights (10% decrease), so the second concentration (24.4 mg/m^3^, adjusted concentration 5.81 mg/m^3^) would be used as the biologically relevant LOAEL and is likely to be only marginally higher than the target BMC (i.e., at 10% RD). It is not clear that the lower concentration can be reasonably interpreted as a NOAEL, so no NOAEL is selected.

## D.2 DOSE-RESPONSE ANALYSIS FOR CANCER

### D.2.1 Supporting Information for Upper Respiratory Tract (Nasal) Cancer Estimates based on Epidemiology Data

#### Life-table Analysis for Nasopharyngeal Cancer (NPC) Risk

A spreadsheet illustrating the calculation for the derivation of the lower 95% bound on the effective concentration associated with a 0.05% extra risk (LEC_0005_) for nasopharyngeal carcinoma (NPC) incidence based on data in Beane Freeman et al. (2013) is presented in Table D-25.

Table D-25 Extra risk calculation^a^ for environmental exposure to 0.0550 ppm formaldehyde (the LEC_0005_ for NPC incidence)^b^ using a log-linear exposure-response model based on the cumulative exposure trend results of Beane Freeman (2013), as described in Section 5.2.1

A | B | C | D | E | F | G | H | I | J | K | L | M | N | O | P
Interval number (i) | Age interval | All-cause mortality (×10^5^/yr) | NPC incidence (×10^5^/yr) | All cause hazard rate (h*) | Prob of surviving interval (q) | Prob of surviving up to interval (S) | NPC cancer hazard rate (h) | Cond prob of NPC incidence in interval (Ro) | Exp duration mid interval (xtime) | Cum exp mid interval (xdose) | Exposed NPC hazard rate (hx) | Exposed all cause hazard rate (h*x) | Exposed prob of surviving interval (qx) | Exposed prob of surviving up to interval (Sx) | Exposed cond prob of NPC in interval (Rx)
1 | <1 | 623.4 | 0.02 | 0.0062 | 0.9938 | 1.0000 | 0.00000 | 0.000000 | 0 | 0.0000 | 0.0000 | 0.0062 | 0.9938 | 1.0000 | 0.00000
2 | 1-4 | 26.5 | 0.05 | 0.0011 | 0.9989 | 0.9938 | 0.00000 | 0.000002 | 0 | 0.0000 | 0.0000 | 0.0011 | 0.9989 | 0.9938 | 0.00000
3 | 5-9 | 11.5 | 0.06 | 0.0006 | 0.9994 | 0.9927 | 0.00000 | 0.000003 | 0 | 0.0000 | 0.0000 | 0.0006 | 0.9994 | 0.9927 | 0.00000
4 | 10-14 | 14.3 | 0.11 | 0.0007 | 0.9993 | 0.9922 | 0.00001 | 0.000005 | 0 | 0.0000 | 0.0000 | 0.0007 | 0.9993 | 0.9922 | 0.00001
5 | 15-19 | 49.4 | 0.15 | 0.0025 | 0.9975 | 0.9915 | 0.00001 | 0.000007 | 2.5 | 0.4182 | 0.0000 | 0.0025 | 0.9975 | 0.9915 | 0.00001
6 | 20-24 | 86.5 | 0.17 | 0.0043 | 0.9957 | 0.9890 | 0.00001 | 0.000008 | 7.5 | 1.2547 | 0.0000 | 0.0043 | 0.9957 | 0.9890 | 0.00001
7 | 25-29 | 96.0 | 0.18 | 0.0048 | 0.9952 | 0.9847 | 0.00001 | 0.000009 | 12.5 | 2.0911 | 0.0000 | 0.0048 | 0.9952 | 0.9847 | 0.00001
8 | 30-34 | 110.2 | 0.30 | 0.0055 | 0.9945 | 0.9800 | 0.00002 | 0.000015 | 17.5 | 2.9276 | 0.0000 | 0.0055 | 0.9945 | 0.9800 | 0.00002
9 | 35-39 | 138.8 | 0.54 | 0.0069 | 0.9931 | 0.9746 | 0.00003 | 0.000026 | 22.5 | 3.7641 | 0.0000 | 0.0069 | 0.9931 | 0.9746 | 0.00003
10 | 40-44 | 201.1 | 0.80 | 0.0101 | 0.9900 | 0.9679 | 0.00004 | 0.000039 | 27.5 | 4.6005 | 0.0001 | 0.0101 | 0.9900 | 0.9679 | 0.00005
11 | 45-49 | 324.0 | 1.07 | 0.0162 | 0.9839 | 0.9582 | 0.00005 | 0.000051 | 32.5 | 5.4370 | 0.0001 | 0.0162 | 0.9839 | 0.9582 | 0.00008
12 | 50-54 | 491.7 | 1.48 | 0.0246 | 0.9757 | 0.9428 | 0.00007 | 0.000069 | 37.5 | 6.2734 | 0.0001 | 0.0246 | 0.9757 | 0.9428 | 0.00011
13 | 55-59 | 711.7 | 1.70 | 0.0356 | 0.9650 | 0.9199 | 0.00009 | 0.000077 | 42.5 | 7.1099 | 0.0001 | 0.0356 | 0.9650 | 0.9198 | 0.00013
14 | 60-64 | 1,015.8 | 1.85 | 0.0508 | 0.9505 | 0.8878 | 0.00009 | 0.000080 | 47.5 | 7.9464 | 0.0002 | 0.0509 | 0.9504 | 0.8876 | 0.00014
15 | 65-69 | 1,527.6 | 2.19 | 0.0764 | 0.9265 | 0.8438 | 0.00011 | 0.000089 | 52.5 | 8.7828 | 0.0002 | 0.0765 | 0.9264 | 0.8436 | 0.00017
16 | 70-74 | 2,340.9 | 2.08 | 0.1170 | 0.8895 | 0.7817 | 0.00010 | 0.000077 | 57.5 | 9.6193 | 0.0002 | 0.1172 | 0.8894 | 0.7815 | 0.00016
17 | 75-59 | 3,735.4 | 1.85 | 0.1868 | 0.8296 | 0.6954 | 0.00009 | 0.000059 | 62.5 | 10.4557 | 0.0002 | 0.1869 | 0.8295 | 0.6951 | 0.00013
18 | 80-84 | 6,134.1 | 1.86 | 0.3067 | 0.7359 | 0.5769 | 0.00009 | 0.000046 | 67.5 | 11.2922 | 0.0002 | 0.3068 | 0.7358 | 0.5766 | 0.00011
| | | | | | | Ro = | 0.000662 | | | | | | Rx = | 0.001163
Extra Risk = (Rx–Ro)/(1–Ro) = 0.0005

- Column A: Interval index number (i).
- Column B: 5-year age interval (except <1 and 1–4) up to age 85.
- Column C: All-cause mortality rate for interval i (× 105/year) (2010 data from NCHS).
- Column D: NPC incidence rate for interval i (× 105/year) (2000-2010 SEER data).
- Column E: All-cause hazard rate for interval i (h*i) (= all-cause mortality rate × number of years in age interval).^c^
- Column F: Probability of surviving interval i without being diagnosed with NPC (qi) (= exp(−h*i)).
- Column G: Probability of surviving up to interval i without having been diagnosed with NPC (Si) (S1 = 1; Si = Si−1 × qi−1, for i>1).
- Column H: NPC incidence hazard rate for interval i (hi) (= NPC incidence rate × number of years in interval).
- Column I: Conditional probability of being diagnosed with NPC in interval i (= (hi/h*i) × Si × (1−qi)), i.e., conditional upon surviving up to interval i without having been diagnosed with NPC [Ro, the background lifetime probability of being diagnosed with NPC, is the sum of the conditional probabilities across the intervals].
- Column J: Exposure duration (in years) at mid-interval (xtime).
- Column K: Cumulative exposure mid-interval (xdose) (= exposure level (i.e., 0.0550 ppm) × 365/240 × 20/10 × xtime) [365/240 × 20/10 converts continuous environmental exposures to corresponding occupational exposures].
- Column L: NPC incidence hazard rate in exposed people for interval i (hxi) (= hi × (1 + β × xdose), where β = 0.04311 + (1.645 × 0.01865) = 0.07379 per ppm × year) [0.04311 per ppm × year is the regression coefficient obtained, along with its SE of 0.01865, from Dr. Beane Freeman (see Section 5.2.1). To estimate the LEC_0005_ (i.e., the 95% lower bound on the continuous exposure giving an extra risk of 0.05%), the 95% upper bound on the regression coefficient is used (i.e., MLE + 1.645 × SE)].
- Column M: All-cause hazard rate in exposed people for interval i (h*xi) (= h*i + (hxi − hi)).
- Column N: Probability of surviving interval i without being diagnosed with NPC for exposed people (qxi) (= exp(−h*xi)).
- Column O: Probability of surviving up to interval i without having been diagnosed with NPC for exposed people (Sxi) (Sx1 = 1; Sxi = Sxi−1 × qxi-1, for i>1).
- Column P: Conditional probability of being diagnosed with NPC in interval i for exposed people (= (hxi/h*xi) × Sxi × (1−qxi)) [Rx, the lifetime probability of being diagnosed with NPC for exposed people = the sum of the conditional probabilities across the intervals].

a Using the methodology of BEIR IV (NRC, 1988).

b The estimated 95% lower bound on the continuous exposure level of formaldehyde that gives a 0.05% extra lifetime risk of NPC.

c For the cancer incidence calculation, the all-cause hazard rate for interval i should technically be the rate of either dying of any cause or being diagnosed with the specific cancer during the interval [i.e., (the all-cause mortality rate for the interval + the cancer-specific incidence rate for the interval – the cancer-specific mortality rate for the interval [so that a cancer case isn’t counted twice, i.e., upon diagnosis and upon death]) × number of years in interval]. This adjustment was ignored here because the NPC incidence rates are small compared to the all-cause mortality rates.

MLE = maximum likelihood estimate; SE = standard error.

### D.2.2 Supporting Information for Upper Respiratory Tract (Nasal) Cancer Estimates based on Animal Data

#### Combining Studies for Dose-response Modeling of Rat Nasal Tumors

The dose-response data from the two long term cancer bioassays using F344 rats (Monticello et al., 1996; Kerns et al., 1983) were statistically evaluated for heterogeneity using EPA’s Categorical Regression software (U.S. EPA, 2000). Data from the two studies were pooled (see Table D-26) and the dose-response analysis was stratified by study. The response was categorized into three severity levels corresponding to the tumor outcome being right censored (0), incidental (1) or fatal (2).

The probability that a severity level, s, or higher will occur is given as a function of exposure concentration and time in terms of a link function H,

Pr ( Y ≥ s ∣ C , t ) = H [a + b_1_ × f 1 ( C ) + b_2_ × f 2 ( t )] (D-17)

where a, b1 and b2 were all allowed to vary across severity levels.

The regression was used to test the null hypothesis that the parameters for intercept (a), exposure concentration (b_1_) and time parameters (b_2_) are statistically equivalent between the severity levels Sev1 and Sev2 at a select p value (> 0.05). As indicated in Table D-27, the analyses were carried out in multiple ways: with and without including time as a parameter (i.e., considering the individual time to tumor data or the summary data, respectively), and also collapsing the incidental (I) and fatal (F) severity levels. Regardless of whether the data are grouped by dose-time or just dose, whether I and F responses are analyzed separately (“I, F”) or lumped (“I-F”) or whether time to tumor is considered, the hypothesis tests indicate that the model parameters derived from the individual studies are equivalent (p > 0.05). This equivalence across parameters indicates that the data from the studies can be combined for dose-response purposes as a mean of achieving greater power in the analysis.

Table D-26 Data used in dose-response modeling of SCC in F344 rat nose^a^

Kerns et al study | | | | | Monticello et al study
Conc(ppm) | Days on study^b^ | Tumor context^c^ | # of animals | Sex | Conc(ppm) | Days on study^b^ | Tumor context^c^ | # of animals | Sex
0 | 182 | 3 | 10 | F | 0 | 1 | 3 | 6 | M
0 | 182 | 3 | 10 | M | 0 | 4 | 3 | 6 | M
0 | 269 | 0 | 1 | F | 0 | 11 | 3 | 6 | M
0 | 365 | 3 | 10 | F | 0 | 39 | 3 | 6 | M
0 | 365 | 3 | 10 | M | 0 | 82 | 3 | 6 | M
0 | 511 | 0 | 1 | F | 0 | 122 | 0 | 1 | M
0 | 558 | 3 | 20 | F | 0 | 182 | 3 | 6 | M
0 | 558 | 3 | 20 | M | 0 | 247 | 0 | 1 | M
0 | 573 | 0 | 1 | F | 0 | 365 | 0 | 1 | M
0 | 608 | 0 | 2 | F | 0 | 365 | 3 | 12 | M
0 | 621 | 0 | 1 | F | 0 | 416 | 0 | 1 | M
0 | 623 | 0 | 1 | M | 0 | 472 | 0 | 1 | M
0 | 629 | 0 | 1 | M | 0 | 530 | 0 | 1 | M
0 | 646 | 0 | 1 | M | 0 | 540 | 0 | 1 | M
0 | 659 | 0 | 1 | F | 0 | 558 | 3 | 10 | M
0 | 679 | 0 | 1 | M | 0 | 568 | 0 | 2 | M
0 | 683 | 0 | 1 | M | 0 | 577 | 0 | 1 | M
0 | 703 | 0 | 1 | F | 0 | 592 | 0 | 1 | M
0 | 715 | 0 | 1 | F | 0 | 611 | 0 | 1 | M
0 | 719 | 0 | 1 | F | 0 | 620 | 0 | 2 | M
0 | 721 | 0 | 1 | F | 0 | 624 | 0 | 1 | M
0 | 728 | 0 | 1 | M | 0 | 628 | 0 | 1 | M
0 | 730 | 3 | 47 | F | 0 | 633 | 0 | 1 | M
0 | 730 | 3 | 54 | M | 0 | 648 | 0 | 1 | M
0 | 770 | 0 | 1 | F | 0 | 677 | 0 | 1 | M
0 | 794 | 0 | 1 | F | 0 | 687 | 0 | 2 | M
0 | 804 | 0 | 1 | F | 0 | 700 | 0 | 1 | M
0 | 819 | 0 | 1 | F | 0 | 702 | 0 | 1 | M
0 | 821 | 3 | 9 | F | 0 | 716 | 0 | 2 | M
0 | 821 | 3 | 10 | M | 0 | 730 | 3 | 21 | M
0 | 826 | 0 | 1 | M | 0.7 | 1 | 3 | 6 | M
0 | 841 | 0 | 1 | F | 0.7 | 4 | 3 | 6 | M
0 | 878 | 0 | 1 | F | 0.7 | 11 | 3 | 6 | M
0 | 878 | 0 | 1 | M | 0.7 | 39 | 3 | 6 | M
0 | 895 | 0 | 1 | M | 0.7 | 65 | 0 | 1 | M
0 | 899 | 0 | 1 | F | 0.7 | 82 | 3 | 6 | M
0 | 911 | 3 | 4 | F | 0.7 | 182 | 3 | 6 | M
0 | 911 | 3 | 6 | M | 0.7 | 365 | 3 | 12 | M
2 | 182 | 3 | 10 | F | 0.7 | 449 | 0 | 1 | M
2 | 182 | 3 | 10 | M | 0.7 | 510 | 0 | 1 | M
2 | 365 | 3 | 10 | F | 0.7 | 526 | 0 | 1 | M
2 | 365 | 3 | 10 | M | 0.7 | 530 | 0 | 1 | M
2 | 482 | 0 | 1 | M | 0.7 | 547 | 0 | 1 | M
2 | 541 | 0 | 1 | M | 0.7 | 558 | 3 | 11 | M
2 | 558 | 3 | 20 | F | 0.7 | 564 | 0 | 1 | M
2 | 558 | 3 | 19 | M | 0.7 | 569 | 0 | 1 | M
2 | 567 | 0 | 1 | F | 0.7 | 598 | 0 | 1 | M
2 | 595 | 0 | 2 | F | 0.7 | 626 | 0 | 1 | M
2 | 597 | 0 | 1 | M | 0.7 | 628 | 0 | 1 | M
2 | 607 | 0 | 1 | F | 0.7 | 633 | 0 | 1 | M
2 | 608 | 0 | 1 | F | 0.7 | 642 | 0 | 1 | M
2 | 628 | 0 | 1 | F | 0.7 | 661 | 0 | 1 | M
2 | 630 | 0 | 1 | M | 0.7 | 670 | 0 | 1 | M
2 | 636 | 0 | 1 | F | 0.7 | 708 | 0 | 1 | M
2 | 639 | 0 | 1 | F | 0.7 | 709 | 0 | 1 | M
2 | 642 | 0 | 1 | M | 0.7 | 713 | 0 | 1 | M
2 | 644 | 0 | 1 | F | 0.7 | 717 | 0 | 1 | M
2 | 645 | 0 | 1 | F | 0.7 | 722 | 0 | 2 | M
2 | 656 | 0 | 1 | M | 0.7 | 730 | 3 | 27 | M
2 | 665 | 0 | 1 | F | 2 | 1 | 3 | 12 | M
2 | 686 | 0 | 1 | F | 2 | 4 | 3 | 6 | M
2 | 687 | 0 | 1 | F | 2 | 11 | 3 | 6 | M
2 | 695 | 0 | 1 | M | 2 | 39 | 3 | 6 | M
2 | 698 | 0 | 1 | M | 2 | 82 | 3 | 6 | M
2 | 713 | 0 | 1 | F | 2 | 182 | 3 | 6 | M
2 | 718 | 0 | 1 | M | 2 | 365 | 3 | 12 | M
2 | 728 | 0 | 1 | F | 2 | 435 | 0 | 1 | M
2 | 730 | 0 | 1 | M | 2 | 472 | 0 | 1 | M
2 | 730 | 3 | 45 | F | 2 | 479 | 0 | 1 | M
2 | 730 | 3 | 50 | M | 2 | 521 | 0 | 1 | M
2 | 744 | 0 | 1 | F | 2 | 558 | 3 | 12 | M
2 | 755 | 0 | 1 | F | 2 | 574 | 0 | 1 | M
2 | 766 | 0 | 1 | F | 2 | 582 | 0 | 1 | M
2 | 767 | 0 | 1 | F | 2 | 590 | 0 | 2 | M
2 | 779 | 0 | 1 | F | 2 | 626 | 0 | 1 | M
2 | 797 | 0 | 1 | F | 2 | 645 | 0 | 1 | M
2 | 809 | 0 | 1 | F | 2 | 675 | 0 | 2 | M
2 | 814 | 0 | 1 | M | 2 | 691 | 0 | 1 | M
2 | 817 | 0 | 1 | F | 2 | 698 | 0 | 1 | M
2 | 821 | 3 | 10 | F | 2 | 705 | 0 | 1 | M
2 | 821 | 3 | 10 | M | 2 | 709 | 0 | 1 | M
2 | 847 | 0 | 1 | M | 2 | 710 | 0 | 2 | M
2 | 869 | 0 | 1 | M | 2 | 730 | 3 | 30 | M
2 | 873 | 0 | 1 | M | 6 | 1 | 3 | 6 | M
2 | 888 | 0 | 1 | F | 6 | 4 | 3 | 6 | M
2 | 909 | 0 | 2 | M | 6 | 11 | 3 | 6 | M
2 | 911 | 3 | 1 | F | 6 | 39 | 3 | 6 | M
2 | 911 | 3 | 4 | M | 6 | 82 | 3 | 6 | M
6 | 182 | 3 | 10 | F | 6 | 116 | 0 | 1 | M
6 | 182 | 3 | 10 | M | 6 | 138 | 0 | 1 | M
6 | 342 | 0 | 1 | F | 6 | 182 | 3 | 6 | M
6 | 362 | 0 | 1 | F | 6 | 330 | 0 | 1 | M
6 | 365 | 3 | 10 | F | 6 | 365 | 3 | 12 | M
6 | 365 | 3 | 10 | M | 6 | 366 | 0 | 1 | M
6 | 367 | 0 | 1 | M | 6 | 421 | 0 | 1 | M
6 | 420 | 0 | 1 | M | 6 | 460 | 0 | 1 | M
6 | 422 | 0 | 1 | M | 6 | 542 | 0 | 1 | M
6 | 519 | 0 | 1 | M | 6 | 547 | 0 | 1 | M
6 | 527 | 0 | 1 | F | 6 | 550 | 0 | 1 | M
6 | 558 | 0 | 1 | M | 6 | 558 | 3 | 12 | M
6 | 558 | 3 | 20 | F | 6 | 566 | 0 | 1 | M
6 | 558 | 3 | 20 | M | 6 | 611 | 0 | 1 | M
6 | 576 | 0 | 1 | M | 6 | 618 | 0 | 1 | M
6 | 592 | 0 | 2 | M | 6 | 626 | 1 | 1 | M
6 | 600 | 0 | 1 | M | 6 | 652 | 0 | 1 | M
6 | 625 | 0 | 1 | M | 6 | 684 | 0 | 1 | M
6 | 643 | 0 | 1 | F | 6 | 688 | 0 | 1 | M
6 | 643 | 0 | 1 | M | 6 | 698 | 0 | 1 | M
6 | 656 | 0 | 1 | F | 6 | 721 | 0 | 1 | M
6 | 659 | 0 | 1 | F | 6 | 722 | 0 | 1 | M
6 | 660 | 0 | 1 | F | 6 | 730 | 3 | 29 | M
6 | 664 | 0 | 1 | F | 10 | 1 | 3 | 6 | M
6 | 667 | 0 | 1 | M | 10 | 4 | 3 | 6 | M
6 | 674 | 0 | 1 | F | 10 | 11 | 3 | 6 | M
6 | 674 | 0 | 1 | M | 10 | 39 | 3 | 6 | M
6 | 681 | 0 | 1 | M | 10 | 82 | 3 | 6 | M
6 | 696 | 0 | 1 | F | 10 | 182 | 3 | 6 | M
6 | 701 | 0 | 1 | F | 10 | 305 | 0 | 1 | M
6 | 701 | 0 | 1 | M | 10 | 365 | 3 | 10 | M
6 | 705 | 0 | 1 | F | 10 | 395 | 0 | 1 | M
6 | 709 | 0 | 1 | F | 10 | 463 | 0 | 1 | M
6 | 712 | 0 | 1 | M | 10 | 466 | 0 | 1 | M
6 | 723 | 0 | 1 | M | 10 | 502 | 0 | 1 | M
6 | 727 | 0 | 2 | F | 10 | 555 | 1 | 1 | M
6 | 727 | 0 | 1 | M | 10 | 558 | 2 | 3 | M
6 | 730 | 0 | 1 | M | 10 | 558 | 3 | 7 | M
6 | 730 | 2 | 1 | F | 10 | 564 | 0 | 1 | M
6 | 730 | 2 | 1 | M | 10 | 568 | 1 | 1 | M
6 | 730 | 3 | 40 | F | 10 | 577 | 0 | 1 | M
6 | 730 | 3 | 40 | M | 10 | 584 | 0 | 1 | M
6 | 748 | 0 | 1 | F | 10 | 590 | 0 | 1 | M
6 | 774 | 0 | 1 | M | 10 | 604 | 0 | 1 | M
6 | 776 | 0 | 1 | F | 10 | 610 | 0 | 1 | M
6 | 776 | 0 | 1 | M | 10 | 617 | 0 | 1 | M
6 | 819 | 0 | 1 | F | 10 | 621 | 1 | 1 | M
6 | 819 | 0 | 1 | M | 10 | 624 | 1 | 1 | M
6 | 821 | 3 | 9 | F | 10 | 626 | 1 | 1 | M
6 | 821 | 3 | 10 | M | 10 | 628 | 0 | 1 | M
6 | 839 | 0 | 1 | F | 10 | 642 | 1 | 2 | M
6 | 839 | 0 | 1 | M | 10 | 655 | 1 | 1 | M
6 | 844 | 0 | 1 | M | 10 | 671 | 0 | 1 | M
6 | 847 | 0 | 1 | M | 10 | 676 | 1 | 1 | M
6 | 890 | 0 | 1 | F | 10 | 687 | 0 | 1 | M
6 | 900 | 0 | 1 | F | 10 | 687 | 1 | 1 | M
6 | 911 | 3 | 5 | F | 10 | 697 | 0 | 1 | M
6 | 911 | 3 | 3 | M | 10 | 709 | 1 | 1 | M
15 | 6 | 0 | 1 | M | 10 | 730 | 2 | 8 | M
15 | 182 | 3 | 10 | F | 10 | 730 | 3 | 12 | M
15 | 182 | 3 | 10 | M | 15 | 1 | 3 | 6 | M
15 | 253 | 0 | 1 | F | 15 | 4 | 3 | 6 | M
15 | 275 | 0 | 1 | M | 15 | 11 | 3 | 6 | M
15 | 320 | 0 | 1 | F | 15 | 39 | 3 | 6 | M
15 | 354 | 0 | 1 | M | 15 | 82 | 3 | 6 | M
15 | 359 | 1 | 1 | F | 15 | 182 | 3 | 9 | M
15 | 362 | 0 | 1 | F | 15 | 220 | 0 | 1 | M
15 | 365 | 1 | 1 | F | 15 | 251 | 0 | 1 | M
15 | 365 | 3 | 10 | F | 15 | 277 | 0 | 1 | M
15 | 365 | 3 | 10 | M | 15 | 278 | 0 | 1 | M
15 | 391 | 0 | 1 | M | 15 | 302 | 0 | 1 | M
15 | 421 | 1 | 1 | F | 15 | 344 | 1 | 1 | M
15 | 433 | 0 | 2 | M | 15 | 348 | 1 | 1 | M
15 | 441 | 1 | 1 | F | 15 | 365 | 2 | 2 | M
15 | 475 | 0 | 1 | M | 15 | 365 | 3 | 14 | M
15 | 478 | 0 | 1 | F | 15 | 372 | 1 | 3 | M
15 | 480 | 0 | 1 | M | 15 | 387 | 1 | 1 | M
15 | 480 | 1 | 1 | F | 15 | 400 | 1 | 1 | M
15 | 489 | 1 | 1 | F | 15 | 466 | 0 | 1 | M
15 | 492 | 0 | 1 | M | 15 | 466 | 1 | 1 | M
15 | 496 | 0 | 1 | M | 15 | 472 | 1 | 1 | M
15 | 505 | 0 | 1 | F | 15 | 479 | 0 | 1 | M
15 | 505 | 1 | 1 | M | 15 | 479 | 1 | 1 | M
15 | 509 | 1 | 1 | F | 15 | 483 | 1 | 1 | M
15 | 510 | 0 | 1 | F | 15 | 493 | 1 | 1 | M
15 | 512 | 0 | 1 | M | 15 | 498 | 1 | 1 | M
15 | 513 | 1 | 1 | F | 15 | 499 | 0 | 1 | M
15 | 521 | 1 | 1 | F | 15 | 500 | 1 | 1 | M
15 | 526 | 1 | 1 | F | 15 | 505 | 1 | 1 | M
15 | 531 | 0 | 1 | M | 15 | 507 | 1 | 2 | M
15 | 532 | 0 | 1 | F | 15 | 513 | 0 | 1 | M
15 | 532 | 1 | 1 | M | 15 | 514 | 1 | 2 | M
15 | 534 | 1 | 2 | F | 15 | 515 | 1 | 2 | M
15 | 536 | 1 | 1 | F | 15 | 519 | 1 | 1 | M
15 | 538 | 0 | 1 | M | 15 | 523 | 1 | 1 | M
15 | 540 | 1 | 1 | M | 15 | 526 | 0 | 1 | M
15 | 544 | 1 | 1 | F | 15 | 526 | 1 | 1 | M
15 | 546 | 0 | 3 | M | 15 | 555 | 1 | 1 | M
15 | 556 | 0 | 1 | M | 15 | 558 | 2 | 6 | M
15 | 558 | 0 | 1 | F | 15 | 558 | 3 | 5 | M
15 | 558 | 1 | 1 | F | 15 | 561 | 1 | 1 | M
15 | 558 | 2 | 4 | F | 15 | 568 | 1 | 1 | M
15 | 558 | 2 | 4 | M | 15 | 575 | 0 | 1 | M
15 | 558 | 3 | 15 | F | 15 | 578 | 0 | 1 | M
15 | 558 | 3 | 15 | M | 15 | 586 | 1 | 1 | M
15 | 561 | 1 | 1 | M | 15 | 591 | 0 | 1 | M
15 | 568 | 1 | 1 | F | 15 | 591 | 1 | 2 | M
15 | 570 | 1 | 1 | M | 15 | 604 | 1 | 1 | M
15 | 572 | 0 | 1 | F | 15 | 614 | 1 | 3 | M
15 | 573 | 1 | 1 | F | 15 | 617 | 1 | 5 | M
15 | 575 | 0 | 2 | M | 15 | 621 | 1 | 1 | M
15 | 575 | 1 | 1 | F | 15 | 635 | 0 | 1 | M
15 | 584 | 0 | 1 | F | 15 | 635 | 1 | 1 | M
15 | 587 | 0 | 1 | F | 15 | 640 | 1 | 1 | M
15 | 589 | 0 | 1 | M | 15 | 645 | 1 | 1 | M
15 | 589 | 1 | 1 | F | 15 | 647 | 0 | 1 | M
15 | 591 | 0 | 1 | F | 15 | 658 | 1 | 1 | M
15 | 596 | 1 | 1 | F | 15 | 661 | 1 | 3 | M
15 | 597 | 1 | 2 | F | 15 | 662 | 1 | 1 | M
15 | 604 | 1 | 1 | F | 15 | 682 | 0 | 1 | M
15 | 607 | 1 | 1 | M | 15 | 695 | 1 | 1 | M
15 | 608 | 0 | 1 | M | 15 | 696 | 1 | 1 | M
15 | 609 | 0 | 1 | M | 15 | 697 | 1 | 1 | M
15 | 610 | 0 | 1 | M | 15 | 698 | 1 | 1 | M
15 | 615 | 0 | 1 | M | 15 | 703 | 1 | 1 | M
15 | 616 | 1 | 1 | F | 15 | 715 | 1 | 1 | M
15 | 621 | 1 | 1 | F | 15 | 721 | 1 | 1 | M
15 | 622 | 1 | 1 | M | 15 | 730 | 2 | 16 | M
15 | 625 | 1 | 1 | F | 15 | 730 | 3 | 8 | M
15 | 628 | 1 | 1 | F
15 | 630 | 0 | 1 | F
15 | 631 | 1 | 1 | M
15 | 632 | 0 | 1 | F
15 | 632 | 0 | 1 | M
15 | 632 | 1 | 1 | M
15 | 642 | 0 | 1 | F
15 | 643 | 1 | 1 | M
15 | 644 | 1 | 1 | F
15 | 645 | 0 | 1 | M
15 | 653 | 1 | 1 | F
15 | 655 | 1 | 1 | M
15 | 664 | 1 | 1 | F
15 | 666 | 1 | 1 | M
15 | 673 | 1 | 1 | F
15 | 674 | 0 | 1 | M
15 | 674 | 1 | 1 | F
15 | 680 | 0 | 1 | F
15 | 680 | 1 | 1 | F
15 | 684 | 1 | 1 | F
15 | 687 | 0 | 2 | M
15 | 687 | 1 | 1 | F
15 | 689 | 0 | 1 | M
15 | 690 | 1 | 1 | F
15 | 694 | 1 | 1 | M
15 | 695 | 0 | 1 | M
15 | 697 | 1 | 1 | F
15 | 700 | 1 | 1 | F
15 | 706 | 1 | 1 | F
15 | 706 | 1 | 1 | M
15 | 707 | 0 | 2 | F
15 | 713 | 1 | 1 | F
15 | 716 | 0 | 1 | M
15 | 718 | 1 | 1 | M
15 | 719 | 0 | 1 | M
15 | 722 | 0 | 1 | M
15 | 722 | 1 | 1 | M
15 | 728 | 1 | 1 | F
15 | 728 | 1 | 2 | M
15 | 730 | 1 | 1 | M
15 | 730 | 2 | 7 | F
15 | 730 | 2 | 3 | M
15 | 730 | 3 | 7 | F
15 | 730 | 3 | 10 | M
15 | 751 | 1 | 1 | M
15 | 754 | 1 | 1 | M
15 | 768 | 1 | 1 | M
15 | 821 | 2 | 2 | M
15 | 821 | 3 | 3 | M

a NTP historical controls used by Conolly et al. (Conolly et al., 2003) not included in this tabulation.

b EPA reproduced the ages of the animals in (Conolly et al., 2003) for the two studies by adding 63 days, the age at beginning of exposure, to the days on study indicated in the CIIT dataset.

c 0- no tumor, non-sacrifice; 1- tumor, non-sacrifice; 2- tumor, sacrifice; 3- no tumor, sacrifice.

Table D-27 Hypothesis testing of parameter equivalence for modeling Monticello et al. (1996); Kerns et al. (1983) studies

Grouping of pooled Kerns & Monticello dose-response data | Best link function^a^ | p-values
Grouping of pooled Kerns & Monticello dose-response data | Best link function^a^ | Sev1; a | Sev2; a | Sev1; b_1_ | Sev2; b_1_ | Sev1; b_2_ | Sev2; b_2_
Study-Dose-Time-Response (C, I, F)^b^ | Probit | 0.06 | 0.99 | 0.71 | 0.99 | -- | --
Study-Dose-Time-Response (C, I, F) | CLogLog | 0.06 | 0.99 | 0.07 | 0.99 | 0.78 | 0.74
Study-Dose-Time-Response (C, I-F)^b^ | Probit | 0.05 | -- | 0.65 | -- | -- | --
Study-Dose-Time-Response (C, I-F) | Probit | 0.87 | -- | 0.97 | -- | 0.25 | --
Study-Dose-Response (C, I, F) | Probit | -- | -- | 0.67 | -- | -- | --
Study-Dose-Response (C, I-F) | Probit | 0.19 | 0.97 | 0.60 | 0.97 | -- | --

a Lowest AIC; Unrestricted Odds (dose and time parameters allowed to vary across severity categories).

b Time data not considered in model.

#### Memo from CIIT Providing Updated Information on Kerns and Monticello studies and NTP Historical Data

For completeness, the CIIT memo related to this modeling (Bermudez, 2004) is included in its entirety below (note: converted from pdf, so there may be minor grammatical errors; the values in tables were confirmed).

[[underlined: Memo Start]]

The purpose of this memorandum is to document the data from the various formaldehyde publications sponsored by or conducted at the CIIT Centers for Health Research (CIIT) and to resolve some data discrepancies and arrive at a final data set that can be used for modeling. This memo includes the total CIIT formaldehyde data set (combined Kerns, Monticello, Everitt) that is available on CD and the information on CIITs use of the NTP control database.

##### Kerns Study (Table 4-7 in 1999 CIIT report)

Updating the data summary for the Kerns et al. (1983) study in the 1999 CIIT report on Page 4-20 to reflect all animals for which there are nasal slides and a consensus of pathology diagnoses, the tumor summary is as follows: 0 animals out of 237 animals at O ppm; 0 out of 239 at 2 ppm; 2 (1Male, 1Female) animals out of 235 at 6 ppm;83(31M,52F)animals outof 225at15ppm.

Concentration | Total Examined | scc Tumors | No Tumors
0 | 237 | 0 | 237
2 | 239 | 0 | 239
6 | 235 | 2 | 233
15 | 225 | 83 | 142

The total examined at all concentrations except the 6 ppm level was increased. These changes correct for what may have been misinterpretations of the incidence numbers presented in the original Kerns report (number of animals on study vs. number of animals examined) and/or limitations in data presented in the Kerns et al. (1983) publication.

##### Monticello Study (Table 7-3 in 1999 CIIT Report)

The following table replaces Table 7-3 in the 1999 CIIT report on Page 7-10 for the data summary of the Monticello et al. (1996) study. The only changes made are for 2 ppm rats where the number of noses examined was 96 not 90. The 90 was a typographical error as an additional 18 animals were examined by Jeff Everitt not 24.

Formaldehyde concentration (ppm)
| 0.0 | 0.7 | 2.0 | 6.01 | 9.93 | 14.94
Monticello et al. (1996); Number SCC; Number examined | 0 | 0 | 0 | 1 | 20 | 69
Monticello et al. (1996); Number SCC; Number examined | 90 | 90 | 96 | 90 | 90 | 147
Additional animals - CIIT (1999) | 0 | 0 | 0 | 0 | 2 | 10
Number SCC; Number examined | 14 | 17 | 18 | 18 | 13 | 14
Total number of SCC | 0 | 0 | 0 | 1 | 22 | 79
Total number of animals examined | 104 | 107 | 114 | 108 | 103 | 161

###### Summary Information

The following table provides a summary of the data for the two studies sponsored or performed by CIIT (Kerns et al., 1983 and Monticello et al., 1996).

###### Summary Table for Kerns and Monticello Studies Combined

Concentration | Total Examined | SCC Tumors | No Tumors
0 | 104 | 0 | 104
.7 | 107 | 0 | 107
2 | 114 | 0 | 114
6 | 108 | 1 | 107
10 | 103 | 22 | 81
15 | 161 | 79 | 82

For control animals, 3,866 males and 3,818 females were used from the NTP historical data base. CIIT classified 13 of 15 NTP classified nasal tumors as nasal SCCs (based on examination by Kevin T. Morgan). The Kerns study examined 237 control animals and the Monticello study, 104 (90 originally and 14 added by Jeff Everitt). No control SCCs were reported in the Kerns or Monticello studies. The total of 8025 for controls and the total examined at other concentrations also includes animals that were very young (prior to the first tumor diagnosis), unscheduled animals and animals that were held for examination up to 6 months beyond the 24-month bioassay. The number of control animals from the CIIT Dataset (available on CD) represents animals for which slides of the nasal cavity are available and may include animals not reported in the Kerns or Monticello published incidence tables. This confirms 13 tumors out of 8025 control animals examined.

Because the biologically-based dose-response (BBDR) model used all of these data, including both bioassays, the additional evaluations by Dr. Jeff Everitt, and the animals that were held post-exposure, any other type of dose-response modeling approaches should attempt to address comparable data sets. As stated above it should be noted that some animals at all concentrations were examined at a very young age (Monticello and Kerns studies, early time points) and this needs to be taken into consideration when using these data.

These data are summarized in the following table.

###### Summary Table for Data Used in Biologically-Based Dose Response (BBDR) Model Developed by the CIIT Centers for Health Research (Conolly et al., 2003)

Concentration | Total Examined | scc Tumors | No Tumors
0 | 8025 | 13 | 8012
0.7 | 107 | 0 | 107
2.0 | 353 | 0 | 353
6.0 | 343 | 3 | 340
10.0 | 103 | 22 | 81
15 | 386 | 162 | 224

##### Conolly Modeling (Appendix Table 1 in 2003 Toxicological Sciences paper)

The time of death due to tumors of the thirteen (13) tumors from the control NTP data are listed in the following table. These dates were used in the BBDR model so that the dates essentially replace the “N/A’ in the first column listed for the control animals in Appendix Table 1 of Conolly et al., (2003). The death dates of the survivor animals were not available and therefore are all estimated and entered as 104.4 weeks for these animals. This assumption was felt justified because of it being such a large data set that the loss of a few animals at other times during their lifetime would not unduly affect their estimate of lifetime nasal SCC probability.

Weeks from start of study | Number of rats with tumors | Cumulative probability
50 | 1 | 0.0001
85 | 1 | 0.0003
87.6 | 1 | 0.0004
91 | 1 | 0.0005
91.9 | 1 | 0.0007
93.7 | 1 | 0.0008
94.9 | 1 | 0.0009
96.6 | 1 | 0.0010
96.9 | 1 | 0.0012
97.6 | 1 | 0.0013
98.1 | 1 | 0.0014
102.3 | 1 | 0.0016
104.4 | 1 | 0.0017

[[underlined: Memo End]]

#### Time-to-tumor Modeling of Rat Nasal Tumor Incidence without Mechanistic Data

The impact of competing risks and interim sacrifices on the nasal tumor incidence needs to be considered in the dose-response analysis because of the strong influence of exposure on survival of animals in the bioassay. The simplest consideration of this factor is to adjust tumor incidences for early deaths according to Kaplan-Meier (K-M) survival estimates (Kaplan and Meier, 1958). This procedure adjusts the total number of animals at a given exposure level (the denominator) to allow for the possibility that some tumors may otherwise have developed in the animals that died early due to other causes. The Kaplan-Meier adjusted incidence (applied only at doses where tumors occur) is shown in Table D-28. The numbers at risk reflect all animals surviving one year on the study and is obtained by dividing the number with observed tumors by the K-M adjusted probability of tumor incidence.

Table D-28 Kaplan-Meier adjusted tumor incidence in the pooled F344 SCC data

Exposure level (ppm) | K-M adjusted incidence | Observed tumors/number at risk^a^
0.0 | 0.0 | 0/242
0.7 | 0.0 | 0/70
2.0 | 0.0 | 0/254
6.0 | 0.0249 | 3/120
10.0 | 0.6144 | 22/36
15.0 | 0.8256 | 157/190

a The denominator is K-M adjusted.

While dose-response modeling of the adjusted summary data in Table D-28 can be carried out, the individual animal data allows for a full time-to-tumor analysis. EPA used the multistage-Weibull (MSW) model (Portier and Bailer, 1989; Krewski et al., 1983; Crouch, 1989) to model the pooled data from the Monticello et al. (1996); Kerns et al. (1983) bioassays along with data from 94 animals that had not been previously examined (Bermudez, 2004). This model has the following form:

P ( d ) = 1 − exp [− (β_0_ + β_1_ d + β_2_ d^2^ + … + β_k_ d^k^) × (t − t_0_) c] (D-18)

where P(d) represents the lifetime risk (probability) of cancer at dose d (i.e., human equivalent exposure in this case); parameters β _i_ ≥ 0, for i = 0, 1, …, k; t is the time at which the tumor was observed; and c is an estimated (fitted) parameter that characterizes the change in response with age. The parameter t_0_ represents the time between when a potentially fatal tumor becomes observable and when it causes death. By including the exact time of observation of the tumors, the model gives appropriate weight to the amount of time each animal was on study without a tumor and acknowledges earlier tumor incidence with increasing dose level.

A further consideration is the distinction between tumor types as being either fatal or incidental in order to adjust for competing risks. Incidental tumors are those tumors thought not to have caused the death of an animal (such as those observed during interim or terminal sacrifices), while fatal tumors are thought to have resulted in animal death. Schlosser et al. (2003) in their modeling of these same data note that the tumors arising in these studies were rapidly growing and quickly lethal and judged that the time to death from tumor would have been only slightly (on the order of weeks) longer than the actual sacrifice times of animals found with tumors. Therefore, it was considered reasonable to consider nasal tumors observed with early deaths to be fatal in the current analysis.

The dose-response analyses were conducted using the MSW module in EPA’s Benchmark Dose software suite which is based on Weibull models drawn from (Krewski et al., 1983). Parameters were estimated using the method of maximum likelihood estimate (MLE). Specific multistage Weibull models were selected for the individual tumor types for each sex, based on the values of the log-likelihoods according to the strategy used by (U.S. EPA, 2002). If twice the difference in log-likelihoods was less than a χ^2^ with degrees of freedom equal to the difference in the number of stages included in the models being compared, the models were considered comparable, and the most parsimonious model (i.e., the lowest-stage model) was selected contingent on visual fits of the data as follows. Goodness of fit p-value was not provided by the software package. Plots of model fits of the parametric MSW model were visually compared with empirical nonparametric Kaplan-Meier (Kaplan and Meier, 1958) estimates fitted to the same data (Figure D-18, Figure D-19, Figure D-20). The empirical nonparametric model is designed to fit the data as “closely” as possible. Consequently, comparisons between the two fitted models provide a subjective assessment for goodness-of-fit of the multistage Weibull model to the data. Both the fitted MSW model and the fitted nonparametric model are displayed on the same graph. If a model with one more stage fitted the low-dose data better than the most parsimonious model, then the model with one higher stage was selected. Table D-29 provides the parameter values for the best fit (labeled model MSW1), and Table D-30 compares relevant parameters with other attempted fits (MSW2 and MSW3) to the data with the multistage Weibull model. The results in Table D-29 and Table D-30 used in conjunction with Figures D-18 through D-22 collectively represent EPA rationale for choosing model MSW1 as the best fit.

It was not possible to obtain model convergence allowing multiple β_i_ parameters to vary; reasonable fits were obtained when, through a process of trial and error, all the β_i_ except β_k_ were fixed at value zero for a MSW model of degree k. The parameter t_0_ was estimated in models MSW2 and MSW3 by fitting the model to the time-tumor data; as seen from the Figures D-21 and D-22 and Table D-30, the fits in these cases were poor. The fit was decidedly superior when t_0_ was fixed to be zero (model MSW1, see Figures D-18 through D-20 and Table D-30), a choice that is consistent with the assumption of rapidly fatal tumors. A sensitivity analysis of this assumption was also carried out by treating all tumors as incidental to the death of the affected animal. This yielded BMCLs and BMCs within 10% of estimates obtained under the rapidly fatal assumption; thus, tumor context does not appear to be a sensitive consideration for these data.

Figure D-18 Dose response for the best fitting multistage Weibull time-to-tumor model (Model MSW1) of pooled rat nasal tumor Plot is at the specified time risk estimates were derived for the benchmark dose calculation

Points compare the nonparametric estimate for the nearest times at the observed doses.

Figure D-19 Probability vs time for the best fitting MSW distribution calculated at each exposure concentration

Points compare with nonparametric estimate; incidental (unfilled), fatal (filled)

Figure D-20 Probabilities from best fitting MSW model plotted against probabilities from the nonparametric model

Plots are shown only for the 6 ppm and 10 ppm data. Each plot point represents the two probabilities at a given observation time. Straight line represents unit slope; goodness of fit can be assessed by how well plotted values align with this line.

Figure D-21 Probability vs time for MSW distribution of model MSW2

Calculations are shown at exposure concentrations of 6 ppm and 10 ppm only for comparison purposes. Points represent nonparametric estimate for comparison; incidental (unfilled), fatal (filled).

Figure D-22 Probabilities from MSW model MSW2 plotted against probabilities from the nonparametric model

Each plot point represents the two probabilities at a given observation time. Straight line represents unit slope; goodness of fit can be assessed by how well plotted values align with this line. Only the 6 ppm and 10 ppm data are plotted.

Table D-29 Multistage-Weibull model fit to combined Kerns and Monticello data, dropping high dose

=======================================================================; Multistage Weibull Model. (Version: 1.6.1; Date: 11/24/2009); Solutions are obtained using donlp2-intv,(c) by P. Spellucci; =======================================================================; MSW model k=5 for Fatal Risk; The form of the probability function is:; P[response]=1-EXP{-(t-t_0)^c*; (beta_0+beta_1*dose^1+beta_2*dose^2+beta_3*dose^3+beta_4*dose^4+beta_5*dose^5; )}; The parameter betas are restricted to be positive; Dependent variable = CLASS; Independent variables = DOSE, TIME; Total number of observations = 222; Total number of records with missing values = 0; Total number of parameters in model = 8; Total number of specified parameters = 6; Degree of polynomial = 5; User specifies the following parameters:; t_0 = 0 ; beta_0 = 0 ; beta_1 = 0 ; beta_2 = 0 ; beta_3 = 0 ; beta_4 = 0; Maximum number of iterations = 64; Relative Function Convergence has been set to: 1e-008; Parameter Convergence has been set to: 1e-008; Default Initial Parameter Values; c = 8.25; t_0 = 0 Specified; beta_0 = 0 Specified; beta_1 = 0 Specified; beta_2 = 0 Specified ; beta_3 = 0 Specified; beta_4 = 0 Specified; beta_5 = 1.61323e-022; Asymptotic Correlation Matrix of Parameter Estimates; ( *** The model parameter(s) t_0,beta_0,beta_1,beta_2,beta_3,beta_4; have been estimated at a boundary point, or have been specified by the user,; and do not appear in the correlation matrix ); ; c beta_5; c 1 -1 ; beta_5 -1 1; Parameter Estimates with 95.0% Wald Confidence Interval; Variable Estimate Std. Err. Conf. Limits; c 8.11916 2.39978 3.41568, 12.8226 ; beta_5 2.94752e-022 3.25917e-021 -6.09311e-021, 6.68262e-021; Log(likelihood) # Param AIC; Fitted Model -90.3034 2 184.607; Data Summary; CLASS; C F I U Total; DOSE; 0 338 0 0 0 338; 0.7 107 0 0 0 107; 2 316 0 0 0 316; 6 301 1 2 0 304; 10 81 11 11 0 103; Minimum observation time for F tumor context = 79.3; Benchmark Dose Computation; Risk Response = Fatal; Risk Type = Extra; Specified effect = 0.1; Confidence level = 0.95; Time = 104; BMD = 6.84417 ; BMDL = 6.34102 ; BMDU = 7.47507

Table D-30 Comparison of parameter estimates in Table D-29 with other Multistage-Weibull model fits to the same data

Model | Multistage degree k | # of est. params | Log-likelihood | AIC | c | t0 | beta^*^
MSW 1 (best fit) | 5 | 2 | −90.3034 | 184.607 | 8.1192 | Fixed at 0.0 | 2.9475e-022
MSW 2 | 5 | 3 | −106.846 | 219.693 | 7.0753 | 11.8365 | 3.6714e-020
MSW 3 | 4 | 3 | −110.048 | 226.095 | 6.9297 | 11.7798 | 5.9254e-019

* coefficient corresponding to the highest non-zero polynomial degree; other polynomial coefficients were set to zero.

#### Estimates from Experimental Animal Studies Using Biologically Based Dose-Response Modeling

Biologically based dose-response (BBDR) models were developed in a series of papers and in a health assessment report by scientists at the Chemical Industry Institutes of Toxicology (CIIT) (Overton et al., 2001; Kimbell et al., 2001b; Kimbell and Subramaniam, 2001; Conolly et al., 2000; Conolly, 2002; Conolly et al., 2003, 2004; CIIT, 1999) to interpret the tumor incidence observed in F344 rats in two long-term bioassays (Monticello et al., 1996; Kerns et al., 1983) and extrapolate risk from rats to humans. The CIIT modeling and available data, and alternatives based on their original model were evaluated extensively for the purpose of this assessment and used in calculating the cancer potency. This section of the appendix separately addresses the BBDR models developed for the F344 rat and the human, and in each case: first provides clarifying details regarding the model, then summarizes all the issues evaluated, and finally provides detailed evaluations of key issues.

##### Model Structure and Calibration in (Conolly et al., 2003, 2004)

In Conolly et al. (2003), tumor incidence data in the above long-term bioassays were modeled by using an approximation of the two-stage clonal growth model (Moolgavkar et al., 1988) and allowing formaldehyde to have directly mutagenic action. Conolly et al. (2003) combined these data with historical control data on 7,684 animals obtained from National Toxicology Program (NTP) bioassays. These models are based on the Moolgavkar, Venzon, and Knudson (MVK) stochastic two-stage model of cancer (Moolgavkar and Venzon, 1979; Moolgavkar and Knudson, 1981; Moolgavkar et al., 1988), which accounts for growth of a pool of normal cells, mutation of normal cells to initiated cells, clonal expansion and death of initiated cells, and mutation of initiated cells to fully malignant cells. The following notations are used in the rest of Appendix D.2.2:

- N cell, normal cell
- I cell, initiated cell
- LI, labeling index (number of labeled cells/(number labeled + unlabeled cells))
- ULLI, unit length labeling index (number labeled cells/length of basement membrane)
- N, number of normal cells that are eligible for progression to malignancy
- α_N_, division rate of normal cells (hours^–1^)
- µ_N_, rate at which an initiated cell is formed by mutation of a normal cell (per cell division of normal cells)
- α_I_, division rate of an initiated cell (hours^–1^)
- β_I_, death rate of an initiated cell (hours^–1^)
- µ_I_, rate at which a malignant cell is formed by mutation of an initiated cell (per cell division of initiated cells)

Cell replication rates and DPX concentrations are driven by local dose, which is formaldehyde flux to each region of nasal tissue expressed as pmol/mm^2^-hour and predicted by computational fluid dynamics (CFD) modeling using anatomically accurate representations of the nasal passages (see Appendix C.1.12). In the CIIT model, cell division and mutation is treated as a function of local flux. The spatial distribution of formaldehyde over the nasal lining was characterized by partitioning the nasal surface by formaldehyde flux to the tissue (rate of gas absorbed per unit surface area of the nasal lining), resulting in 20 “flux bins” with low bin numbers associated with low flux values. Each bin is comprised of elements of the nasal surface, which are not necessarily contiguous, that receive a particular interval of formaldehyde flux per ppm of exposure concentration (Kimbell et al., 2001b). Because formaldehyde mass transfer is airflow-limited, flux is assumed to scale linearly with inhaled exposure concentration (ppm); accordingly, it is expressed in the CFD modeling in (Kimbell et al., 2001b) in terms of pmol/mm^2^-hour-ppm, and the spatial coordinates of elements comprising a particular flux bin are fixed for all exposure concentrations. Table D-31 tabulates the flux bins for the F344 rat. As seen from Table D-31, the nasal surface area attributed to a bin drop sharply with increasing flux bin numbers because there is a decreasing gradient of flux from proximal to distal regions of the nose.

Table D-31 Modeled formaldehyde flux on F344 rat nasal lining (Source: (Kimbell et al., 2001b)

Flux Bin | Flux/ppm ratio (pmol/mm^2^-h-ppm) | Number of cells at risk in adult animals
1 | 5.08E+01 | 3.03E+07
2 | 1.90E+02 | 4.84E+06
3 | 3.25E+02 | 3.20E+06
4 | 4.55E+02 | 2.24E+06
5 | 5.88E+02 | 2.08E+06
6 | 7.18E+02 | 1.28E+06
7 | 8.58E+02 | 1.11E+06
8 | 9.78E+02 | 9.39E+05
9 | 1.11E+03 | 7.89E+05
10 | 1.25E+03 | 6.11E+05
11 | 1.37E+03 | 5.81E+05
12 | 1.51E+03 | 5.01E+05
13 | 1.64E+03 | 5.18E+05
14 | 1.76E+03 | 3.69E+05
15 | 1.90E+03 | 2.79E+05
16 | 2.02E+03 | 9.90E+04
17 | 2.16E+03 | 3.24E+04
18 | 2.28E+03 | 1.44E+04
19 | 2.40E+03 | 1.40E+03
20 | 2.56E+03 | 1.33E+03

Inputs to the model: The inputs to the two-stage cancer modeling consisted of results from other model predictions as well as empirical data. These included: regional uptake of formaldehyde in the respiratory tract predicted by using CFD modeling in the F344 rat and human (Subramaniam et al., 1998; Overton et al., 2001; Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) discussed in Appendix A.2; concentrations of DPXs predicted by a PBPK model (Conolly et al., 2000) calibrated to fit the DPX data in F344 rat and rhesus monkey (Casanova et al., 1991; Casanova et al., 1994) and subsequently scaled up to humans; and cell division rates for normal cells (α_N_) inferred from labeling index data on rats exposed to formaldehyde (Monticello et al., 1990; Monticello et al., 1991; Monticello et al., 1996).

Calibration: The rat model in Conolly et al. (2003) involved six unknown statistical parameters that were estimated by fitting the model to the rat formaldehyde bioassay data shown in Table 2-20 of the main document (Monticello et al., 1996; Kerns et al., 1983) plus historical data from several thousand control animals from all the rat bioassays conducted by the NTP. These NTP bioassays were conducted from 1976 through 1999 and included 7,684 animals with an incidence of 13 SCCs (i.e., 0.17% incidence). The resulting model predicts the probability of a nasal SCC in the F344 rat as a function of age and exposure to formaldehyde. The fit of the Conolly et al. (2003) model to the tumor incidence data is shown in Figure 5-5 of the main document.

Modeling formaldehyde’s mutational action: Formaldehyde interacts with DNA to form DPXs. In Conolly et al. (2003), DPX formation is considered proportional to the intracellular dose of formaldehyde related to its directly mutagenic action. Casanova et al. (1989); Casanova et al. (1994) carried out two studies of DPX measurements in F344 rats. In the first study, rats were exposed to concentrations of 0.3, 0.7, 2, 6, and 10 ppm for 6 hours and DPX measurements were made over the whole respiratory mucosa of the rat, while in the second study, the exposure was to 0.7, 2, 6, or 15 ppm formaldehyde for 3 hours and measurements were made at “high” and “low” tumor sites. Conolly et al. (2000) used data from the second study to develop a PBPK model that predicted the time course of DPX concentrations as a function of regional formaldehyde flux (estimated in the CFD modeling and expressed as pmol/mm^2^-hour). In the two-stage clonal expansion model the mutation rate of normal and initiated cells were defined as the same linear function of DPX concentration as follows:

μ_N_ = μ_I_ = μ_Nbasal_ + KMU × DPX (D-19)

The unknown constants μ_Nbasal_ and KMU were estimated by fitting model predictions to the tumor bioassay data.

Use of labeling data: Cell replication rates in Conolly et al. (2003) were obtained by pooling labeling data from two phases of a labeling study in which male F344 rats were exposed to formaldehyde gas at similar concentrations (0, 0.7, 2.0, 6.0, 10.0, or 15.0 ppm). The first phase employed injection labeling with a 2-hour pulse labeling time, and animals were exposed to formaldehyde for early exposure periods of 1, 4, and 9 days and 6 weeks (Monticello et al., 1991). The second phase used osmotic minipumps for labeling with a 120-hour labeling time to quantify labeling in animals exposed for 13, 26, 52, and 78 weeks (Monticello et al., 1996). The combined pulse and continuous labeling data were expressed as one exposure time-weighted average (TWA) over all sites for each exposure concentration. α_N_ was calculated from these labeling data by using an approximation from Moolgavkar and Luebeck (1992). A dose-response curve for normal cell replication rates (i.e., α_N_ as a function of formaldehyde flux) was then calculated as shown in Figure D-23.

Upward extrapolation of normal cell division rates: The extensive labeling data collected by (Monticello et al., 1991; Monticello et al., 1996) present an opportunity to use precursor data in assessing cancer risk. However, these empirical data were used to determine α_Ν_(flux) only for the lower flux range, 0–9,340 pmol/mm^2^-hour [see Subramaniam et al. (2008) for the reasons], as shown by the solid line in Figure D-23, whereas the highest computed flux at 15.0 ppm exposure was 39,300 pmol/mm^2^-hour. Therefore, Conolly et al. (2003) introduced an adjustable parameter, α_max_, that represented the value of α_Ν_(flux) at the maximum flux of 39,300 pmol/mm ^2^-hour. α_max_ was estimated by maximizing the likelihood of the two-stage model fit to the tumor incidence data. For 9,340 < flux ≤ 39,300 pmol/mm^2^-hour, α_Ν_(flux) was determined by linear interpolation from α_Ν_(9,340) to α_max_, as shown by the dashed line in Figure D-23.

Figure D-23 Dose response of normal (α_N_) and initiated (α_I_) cell division rate in Conolly et al. (2003)

Note: Empirically derived values of α_N_ (TWA over six sites) from Table 1 in Conolly et al. (2003) and optimized parameter values from their Table 4 were used. The main panel is for the J-shaped dose response. Insets show J-shaped and hockey-stick shaped representations at the low end of the flux range. The long arrow denotes the upper end of the flux range for which the empirical unit-length labeling data are available for use in the clonal growth model. α_max_ is the value of α_N_ at the maximum formaldehyde flux delivered at 15 ppm exposure and estimated by optimizing model fit to the tumor incidence data. α_I_ < α_N_ for flux greater than the value indicated by the small vertical arrow. (Conolly et al., 2003, 2004) assumed β_I_ = α_N_ at all flux values.

Source: Subramaniam et al. (2008).

Division and death rates of initiated cells: The pool of cells used for obtaining the LI data in (Monticello et al., 1991; Monticello et al., 1996) consists of largely normal cells, and it may be expected that there would be increasing numbers of initiated cells at higher exposure concentrations. Because the division rates of initiated cells in the nasal epithelium, α_I_, either background or formaldehyde exposed, could not be inferred from the available empirical data, Conolly et al. (2003) assumed a two-parameter function to link α_I_ to α_N_

α_I_ = α_N_ × {multb − multc × max [α_N_ − α_N ( basal )_ , 0]} (D-20)

where α_N_ ≡ α_N_(flux), α_N(basal)_ is the estimated average cell division rate in unexposed normal cells, and multb and multc are unknown parameters estimated by likelihood optimization against the tumor data.^32^ The value of α_N(basal)_ was equal to 3.39 × 10^–4^ hours^–1^ as determined by Conolly et al. (2003) from the raw averaged unit length labeling index data. The ratio α_I_:α_N_ decreases with flux approximately from 1.07 to 0.96 over the flux range used in the modeling (see Figure 6 in (Subramaniam et al., 2008)).

Death rates of Initiated cells (β_I_) are assumed to equal the division rates of normal cells (α_N_) for all formaldehyde flux values, that is

β_I_ ( flux ) = α_N_ ( flux ) (D-21)

No biological justification for these assumed relationships was provided by the authors. Conolly et al. (2003) stated that this formulation for α_I_ and β_I_ provided the best fit of the model to the tumor data.

Structure of the CIIT human model: Subsequent to the BBDR model for modeling rat cancer, Conolly et al. (2004) developed a corresponding model for humans for the purpose of extrapolating the nasal cancer risk estimated by the rat model to humans. Also, rather than considering only nasal tumors (as in the rat model), the human extrapolation model was used to predict the risk of all human respiratory tumors. The human extrapolation model is conceptually very similar to the rat model, and is based on an anatomically realistic representation of the human nasal passages in a single individual and an idealized representation of the LRT. Local formaldehyde flux to the tissue is estimated by a CFD model for humans (Subramaniam et al., 1998; Overton et al., 2001; Kimbell et al., 2001b). However, the model does not incorporate any data on human responses to formaldehyde exposure.

Rates of cell division and cell death are, with a minor modification, assumed to be the same in humans as in rats. The concentration of formaldehyde-induced DPXs in humans is estimated by scaling up from values obtained from experiments in the F344 rat and rhesus monkey.

The statistical parameters for the human model are either estimated by fitting the model to the human background data, assumed to have the same value as obtained in the rat model, or, in one case, fixed at a value suggested by the epidemiologic literature. The delay, D, is fixed at 3.5 years, based on a fit to the incidence of lung cancer in a cohort of British doctors (Doll and Peto, 1978). The two other parameters in the rat model that affect the background rate of cancer (multb and µ_basal_) are estimated by fitting to U.S. cancer incidence or mortality data. These parameters affect the baseline values for the human α_I_, µ_N_, and µ_I_. Because α_max_, multfc, and KMU do not affect the background cancer rate, they cannot be estimated from the (baseline) U.S. cancer incidence rates. Therefore, in (Conolly et al., 2003, 2004), α_max_ and multfc are assumed to have the same values in humans as in rats, and the human value for KMU is obtained by assuming that the ratio KMU:µ_basal_ is invariant across species. Thus,

K M U_( h u m a n )_ = K M U_( r a t )_ × (μ_N b a s a l ( h u m a n )_)/(μ_N b a s a l ( r a t )_) (D-22)

##### Evaluation of Conolly et al. (2003) Modeling of Nasal Cancer in the F344 Rat and Alternative Implementations

Table 5-39 in the dose-response section of the main document listed various issues that were evaluated by EPA pertaining to the BBDR modeling. An overview of that evaluation is first provided here, following which only the following four major issues are further elaborated: physiologically based pharmacokinetic modeling of DPXs, use of historical controls, the uncertainty and variability in the dose response for normal cell-replication rates, and sensitivity of model results to uncertainty in the kinetics of initiated cells.

###### Summary of Issues Evaluated in the Rat BBDR Modeling

Table D-32 summarizes model uncertainties and their impact as evaluated by EPA and points the reader to sections of this document or published manuscripts (Subramaniam et al., 2007; Subramaniam et al., 2008; Crump et al., 2008) where key uncertainties are discussed in more detail. The results in Subramaniam et al. (2007) and Crump et al. (2008) have been debated further in the literature (Crump et al., 2009; Conolly et al., 2009). Other alternatives to the CIIT biological modeling (but based on that original model) are also further explored and evaluated below.

Table D-32 Evaluation of assumptions and uncertainties in the CIIT model for nasal tumors in the F344 rat

| Assumptions, approach, and characterization of input data in model^a^ | Rationale for assumption/approach | EPA evaluation | Further elaboration of evaluation
1 | Steady-state flux estimates are not affected by airway and tissue reconfiguration due to long-term dosing. | Histopathologic changes not likely to be rate-limiting factors in dosimetry. | 1) Thickening of epithelium and squamous metaplasia occurring at later times for the higher dose (Kimbell et al., 1997a) will reduce tissue flux. Not incorporated in model.; 2) These effects will push regions of higher flux to more posterior regions of respiratory tract. Likely to affect calibration of rat model. Uncertainty not evaluated quantitatively.; 3) Calibration of PBPK model for DPXs was seen to be highly sensitive to tissue thickness. | Subramaniam et al. (2008); Cohen Hubal et al. (1997); Klein et al. (2011)
2 | DPX is dose surrogate for formaldehyde’s mutagenic potential. DPX clearance is rapid and complete in 18 hrs. | Casanova et al. (1994). | Half-life for DPX clearance in in vitro experiments on transformed cell lines was 7 times longer than estimated by (Conolly et al., 2003, 2004) and perhaps 14 times longer with normal (nontransformed) human cells. In vivo studies Lai (2016) indicate a slow repair of DPX. Some DPX accumulation is therefore likely. However, model calibration and dose response in rat was insensitive to this uncertainty. | Quievryn and Zhitkovich (2000); Subramaniam et al. (2007); D.2.2
3 | Formaldehyde’s mutagenic action takes place only while DPX’s are in place. | | DNA lesions may remain after DPX repair and incomplete repair of DPX can lead to mutations (Barker et al., 2005). There is some potential for formaldehyde-induced mutation after DPX clearance. Thus, it is possible that formaldehyde mutagenicity may be underrepresented in model. Could not quantitatively evaluate uncertainty (no data on clearance of secondary lesions). | Subramaniam et al. (2008);
4 | Hoogenveen et al. (1999) solution method, which is valid only for time-independent parameters, is accurate enough. | Errors due to this assumption thought to be significant only at high concentration and not at human exposures. | EPA implemented a solution method valid for time-dependent parameters. Results did not differ significantly from those obtained assuming Hoogenveen et al. (1999) solutions. However, impact was not evaluated for the case where cell replication rates vary in time. | Crump et al. (2005); Subramaniam et al. (2007)
5 | All observed SCC tumors are rapidly fatal; none are incidental tumors. | Death is expected to occur typically within 1–2 weeks of observed tumor (personal communication with R. Conolly). | 1) Overall, assumption does not impact model calibration or prediction.; 2) However, because 57 animals were observed to have tumors at interim sacrifice times, EPA implementation of this model distinguished between incidental and fatal tumors. Time lag between observable tumor and time of death was significant compared to time lag between first malignant cell and observable tumor. | Subramaniam et al. (2007)
6 | Historical controls from entire NTP database were lumped with concurrent controls in studies. | Large number of control animals (7,684). Intercurrent mortality was not expected to be substantial. | 1) Tumor incidence in “all NTP” 10-fold higher than in “all inhalation NTP” controls. Including all NTP controls is considered inappropriate.; 2) Low-dose-response curve is very sensitive to use of historical controls.; 3) Large impact on parametrizations and predictions from corresponding human extrapolation model. | Subramaniam et al. (2007); Crump et al. (2008); D.2.2; Table D-35; Table D-40; Figure D-38
7a | LI was derived from experimentally measured ULLI. | Derived from correlating ULLI to LI measured in same experiment. | Significant variation in number of cells per unit length of basement membrane. Spread in ULLI/LI ≈25%. Impact on risk not evaluated. | Subramaniam et al. (2008)
7b | Pulse and continuous labeling data were combined in deriving α_N_ from LI. | All continuous LI values were normalized by mean ratio of pulse to continuous LI for controls. | Formula used for deriving α_N_ from LI is not applicable for pulse labeling data. Pulse labeling is measure of number of cells in S-phase, not of their recruitment rate into S-phase; not enough information to derive α_N_ from pulse data. Impact on risk predictions could not be evaluated. | Subramaniam et al. (2008); D.2.2
7c | To construct dose response for α_N_, labeling data were weighted by exposure time (t) and averaged over all nasal sites (TWA). For a given exposure concentration, flux was then averaged over all nasal sites. | Site-to-site variation in LI was large and did not vary consistently with flux. No reasonable approach was available for extrapolating observed time variation in labeling in rats to humans. | 1) TWA assigns low weight to early time LI values, but α_N_ for early time (t) is very important to the cancer process. Because pulse ULLI was used for t < 13 wks, impact of these ULLIs on risk could not be evaluated.; 2) Time dependence in α_N_ derived from continuous ULLI does not significantly impact model predictions.; 3) Site-to-site variation of α_N_ is at least 10-fold and has major impact on model calibration. Variation in tumor incidence data across sites is 10-fold.; 4) Large differences in number of cells across nasal sites, so averaging over sites is problematic.; 5) TWA is also problematic because histologic changes, thickening of epithelium and metaplasia occur at later times for the higher dose and would affect replication rate. | Subramaniam et al. (2008); D.2.2, Table D-40, Figures D-21 to D-33
7d | TWA α_N_(flux) rises above baseline levels only at cytolethal dose. Above such dose, α_N_(flux) rises sharply due to regenerative proliferation. | Variability in α_N_(flux) is partly represented by also considering hockey-stick (threshold in dose) when TWA indicates J-shaped (inhibition of cell division) description of α_N_(flux). | 1) Uncertainty and variability in α_N_ were quantitatively evaluated to be large. In addition, there are several qualitative uncertainties in characterization of α_N_(flux) from LI.; 2) Several dose-response shapes, including a monotonic increasing curve without a threshold, were considered in order to adequately describe highly dispersed cell replication data. This has substantial impact on low dose risk. | Subramaniam et al. (2008); D.2.2, Figures D-21 to D-33, Figure D-42.
8a | Dose response for α_I_ was obtained from α_N_, assuming ratio (α_I_:α_N_) to be a twoparameter function of flux (equation D-20). Parameters were estimated by optimizing model predictions against tumor incidence data. | (α_I_:α_N_) was >1.0 in line with the notion of I cells possessing a growth advantage over N cells. Assumption satisfies Occam’s razor principle (Conolly et al., 2009). | 1) α_I_:α_N_ in CIIT modeling is <1.0 (growth disadvantage) for higher flux values and is >1.0 only at lower end of flux range in model (Figure D-23).; 2) Because there are no data to inform α_I_, sensitivity of risk estimates to various functional forms was evaluated. Risk estimates for the rat were extremely sensitive to alternate biologically plausible assumptions for α_I_(flux) and varied by many orders of magnitude below concentrations with observable tumors, including values lower than baseline risk. All these models described tumor incidence data and cell replication and DPX data equally well. | Subramaniam et al. (2008); Crump et al. (2008); Crump et al. (2009); D.2.2, Figures D-36, D-37; Tables D-37, D-38.
8b | Death rate of I cells is assumed equal to division rate of N cells i.e., β_I_(flux) = α_N_(flux). (equation D-21) | Based on homeostasis (α_N_ = β_N_) and assumption that formaldehyde is equally cytotoxic to N cells and I cells. Assumption satisfies Occam’s razor principle (Conolly et al., 2009). | 1) In general, data indicate I cells are more resistant to cytolethality and that ADH3 clearance capacity is greater in transformed cells. Therefore, β_I_ = α_N_ is a tenuous model assumption.; 2) Alternate assumption, β_I_ proportional to α_I_, was examined. Risk estimates were extremely sensitive to assumptions on β_I_. | Subramaniam et al. (2008); Crump et al. (Crump et al., 2009); Crump et al. (2008); D.2.2, Figures D-36, D-37; Table D-37.

a (Conolly et al., 2003, 2004).

Given the scope of issues to examine, the evaluation of the BBDR modeling as presented in Conolly et al. (2003), and in alternative approaches considered by EPA, proceeded in stages. First, the dosimetric models for formaldehyde flux and DPXs were evaluated. Confidence in the CFD modeling of formaldehyde flux has been assessed in the toxicokinetic modeling section earlier, and is not repeated here. The evaluation of PBPK models for predicting DPXs is presented below.

Second, the Hoogenveen et al. (1999) solution was replaced by one that is valid for a model with time-varying parameters [Crump et al. (2005), and tumors found at scheduled sacrifices were assumed to be incidental rather than fatal (see Table D-32 and Subramaniam et al. (2007)). Third, PBPK model-predicted weekly averaged solutions for DPX concentration levels were used instead of hourly varying solutions (see Figure 1 and Appendix A in (Subramaniam et al., 2007)). The log-likelihood values and tumor probabilities remained essentially unchanged. Upon quantitative evaluation, these factors, although important from a methodological point of view, were not found to be major determinants of either calibration or prediction of the model for the F344 rat data (Subramaniam et al., 2007). EPA evaluation first attempted to reproduce the Conolly et al. (2003) results under similar conditions and assumptions, including the assumption that tumors were rapidly fatal. Figure 5-5 of the main document shows the results from Conolly et al. (2003) and the predicted probabilities from Subramaniam et al. (2007) (source code made available by Dr. Conolly). These are compared with the best-fitting model and plotted against the Kaplan-Meier (KM) probabilities. Although the results are largely similar, there are some residual differences, and these are detailed in Subramaniam et al. (2007).

Following Georgieva et al. (2003), Subramaniam et al. (2007) used the DPX clearance rate constant obtained from in vitro data instead of the assumption in Conolly et al. (2003) that all DPXs cleared within 18 hours (Subramaniam et al., 2007). With this revision, weekly average DPX concentrations were larger than those in Conolly et al. (2003) by essentially a constant ratio equal to 4.21 (range of 4.12–4.36) when averaged over flux bin and exposure concentrations. Cancer model fits to the rat tumor incidence data using the two sets of DPX concentrations (everything else remaining the same) provided very similar parameter estimates, except that the parameter KMU_rat_ in equation D-19 was 4.23 times larger with the Conolly et al. (2003) DPX concentrations. In other words, the product KMU × DPX remained substantially unchanged. However, it is important to note that the different clearance rate does significantly impact the scale-up of the two-stage clonal growth model to the human because the parameter KMU_human_ is not estimated separately but related to KMU_rat_ (see equation D-22).

After making the above modifications, the impact of the other uncertainties in Table D-32 were examined; only three uncertainties had large impacts on the modeling of the F344 rat data. These uncertainties and the evaluation of the PBPK modeling of DPX will be discussed in more detail below:

1) evaluation and model selection of PBPK models for DPX,
2) use of historical controls,
3) uncertainty and variability in characterizing cell replication rates from the labeling data, and
4) uncertainty in model specification of initiated cell kinetics.

##### Physiologically based pharmacokinetic models for DPX: evaluation and model selection

The CFD modeling discussed in the toxicokinetics section models the transport of formaldehyde through the air phase to the tissue lining on the respiratory tract. While these calculations involved the specification of boundary conditions that appropriately characterize the air-tissue interface, the internal dose of formaldehyde and its reaction with tissue constituents was not explicitly modeled. Several physiologically based pharmacokinetic (PBPK) models have been developed to describe the disposition of formaldehyde in the tissue accounting for formaldehyde reaction via saturable and first order pathways that include the formation and, in some models clearance, of DNA protein cross links (DPX) formed by formaldehyde. These models relied wholly or partly on various experimental measurements of DPX in the upper respiratory tract of the F344 rat and rhesus monkey and in the lower respiratory tract of the rhesus monkey (Casanova et al., 1989; Casanova et al., 1991; Casanova et al., 1994), which were discussed earlier in Appendix C.1. The measurements, and subsequently the models that were based upon these data, allowed the use of formaldehyde-DPX as an internal dosimeter of inhaled formaldehyde, in particular, as a surrogate for the molecular dose associated with formaldehyde’s mutagenic potential. These models are tabulated below in Table D-33.

Table D-33 PBPK models for formaldehyde-DPX

Model | Dpx data | Animal species | Human extrapolation model | Compartments and pathways | Includes airphase formaldehyde flux?
Casanova et al. (1991) | Casanova et al. (1989); 6-hr exp; 0.3, 0.7, 2.0, 6.0, 10 ppm; Casanova et al. (1991); 6-hr exp; 0.7, 2.0, 6.0 ppm | F344 rat; Rhesus monkey | No | Single well-stirred compartment. Saturable & 1^st^ order metabolism, 1^st^ order DPX formation but not clearance. | No
Heck & Casanova (1994) | Casanova et al. (1994); 0.7, 2, 6, 15 ppm preexposed + naïve groups | F344 rat | No | Similar to Casanova et al. (1991). Included effects of preexposure, induction of hyperplasia at conc > 6 ppm. | No
Cohen Hubal et al. (1997) | Casanova et al. (1989) above + Casanova (1994); 3-hr exp; 0.7, 2.0, 6.0, 15 ppm | F344 rat | No | Casanova (1991) model+air-phase transport+ 1^st^ order DPX clearance. Predicted DPX in a more localized region based on model calibrated over whole nose | Yes (Kimbell et al., 1997a)
Conolly et al. (2000) | Casanova et al. (1989) above + Casanova (1994); 3-hr exp, 0.7, 2.0, 6.0, 15 ppm; Casanova et al. (1991); 6-hr exp; 0.7, 2.0, 6.0 ppm | F344 rat; Rhesus monkey | Yes | Similar to Cohen Hubal et al. (1997). Derived allometric rule based on rat and rhesus model to develop human extrapolation model | Yes (Kimbell et al., 2001b)
Georgieva et al. (2003) | Casanova et al. (1989) above + Casanova (1994) 3 hr exp, 0.7, 2.0, 6.0, 15 ppm | F344 rat | No | Multilayer tissue compartment, epithelia of varying thickness. Saturable & 1^st^ order metabolism, 1^st^ order DPX formation & clearance, clearance rate derived from in vitro data | Yes, (Kimbell et al., 2001b
Franks et al. (2005) | Did not use data on DPX or formaldehyde levels for calibration. Parameter values from other models were used. | Model developed for humans | | Continuous distribution of formaldehyde across mucous, epithelial & blood perfused submucosal layers; diffusional transport of formaldehyde through mucous layer; Saturable & 1^st^ order metabolism, 1^st^ order DPX formation but not clearance. Model evaluated systemic transport of formaldehyde. | No
Subramaniam et al. (2007) | Casanova et al. (1989) above + Casanova (1994) 3 hr exp, 0.7, 2.0, 6.0, 15 ppm. | F344 rat | No | Saturable & 1^st^ order metabolism, 1^st^ order DPX formation & clearance, clearance rate derived from in vitro data | Yes, (Kimbell et al., 2001b

In addition, Klein et al. (2011) used Conolly et al. (2000) as a case study to demonstrate approaches for uncertainty analyses of PBPK modeling for situations involving limited time course data. Of the models in Table D-33, clearance of DPX by repair processes was not considered in Casanova et al. (1991), Heck and Casanova (1994) and Franks et al. (2005), and only Conolly et al. (2000) extended their animal PBPK model to develop a corresponding model for the human. The Conolly et al. (2000) modeling presents other features that are useful in the context of modeling formaldehyde dose response. Their PBPK modeling of DPX kinetics explicitly incorporates regional formaldehyde dosimetry in the nasal lining by using results from CFD modeling of airflow and gas uptake. Furthermore, results from their models were used as input to biologically based cancer dose-response (BBDR) modeling developed by the same authors. Because of these reasons, EPA evaluated the Conolly et al. (2000) PBPK effort, following which it was modified (see Appendix A in Subramaniam et al. (2007)) and used in EPA’s dose-response assessment. The Conolly et al. (2000) model is first described below.

In earlier risk assessment efforts by Hernandez et al. (1994) and Casanova et al. (1991), the average DPX concentration was considered a surrogate tissue dose metric for the area-under-the-curve (AUC) of the reactive formaldehyde species. Conolly et al. (2003) assigned a more specific role for DPXs, treating local DPX concentration as a dose surrogate indicative of the intercellular concentration of formaldehyde leading to formaldehyde-induced mutations. These authors indicated that it was not known whether DPXs directly induced mutations (Merk and Speit, 1998; Conolly et al., 2003). The Conolly et al. (2000) model consists of a single well-mixed compartment for the nasal lining as follows:

1) Formaldehyde flux to a given region of the nasal lining is provided as input to the modeling and is obtained in turn as the result of a CFD model. This flux is defined as the amount of formaldehyde delivered to the nasal lining per unit time per unit area per ppm of concentration in the air in a direction transverse to the airflow. It is locally defined as a function of location in the nose and the inspiratory flow rate and is linear with exposure concentration.
2) The clearance of formaldehyde from the tissue is modeled as a saturable pathway representing enzymatic metabolism of formaldehyde primarily by formaldehyde dehydrogenase (involving Michaelis-Menten parameters Vmax and K_m_); a separate first-order pathway, which is assumed to represent the intrinsic reactivity of formaldehyde with tissue constituents (rate constant k_f_); and a first-order binding to DNA that leads to DPX formation (rate constant k_b_).
3) The clearance or repair of DPX is modeled as a first order process (rate constant k_loss_).

DPX concentrations were estimated from a study by Casanova et al. (1994) in which rats were exposed 6 hours/day, 5 days/week, plus 4 days for 11 weeks to filtered air (naive) or to 0.7, 2, 6, or 15 ppm (0.9, 2.5, 7.4, or 18 mg/m^3^) formaldehyde (preexposed). On the 5th day of the 12th week, the rats were then exposed for 3 hours to 0, 0.7, 2, 6, or 15 ppm 14C-labeled formaldehyde (with preexposed animals exposed to the same concentration as during the preceding 12 weeks and 4 days). The animals were sacrificed and DPX concentrations determined at two sites in the nasal mucosa. Conolly et al. (2000) used these naive rat data to develop a PBPK model that predicted the time-course of DPX concentrations as a function of formaldehyde flux at these sites.^33^

Casanova et al. (1994) observed that the DPX concentrations measured in the preexposed animals (exposed for 11.5 weeks) were not significantly higher than those in naïve (air-exposed control) animals in which there was no significant DPX accumulation. This was interpreted to mean that DPX repair is rapid enough to completely eliminate the DPX formed in a single 6-hour exposure by the beginning of the next day. Based on this observation, Conolly et al. (2000) assumed a value of 6.5 × 10^−3^ minute^−1^ for kloss, the first-order rate constant for the clearance (repair) of DPXs, such that the DPXs predicted at the end of a 6-hour exposure to 15 ppm were reduced to exactly the detection limit for DPXs in 18 hours.

###### Uncertainties in PBPK Modeling of the Rat and Rhesus DPX Data

The above assumption of rapid DPX repair in Conolly et al. (2000) appears to be questionable on three grounds. First, in vitro data from three human cell lines indicated a much slower clearance, with an average kloss of 9.24 × 10^−4^ minute^−1^ (Quievryn and Zhitkovich, 2000). While the in vitro data can be uncertain because these cells were transformed and immortalized, it appears that DPX repair in normal cells would be even slower. When nontransformed freshly purified human peripheral lymphocytes were used instead, the half-life for DPX repair was about 50% longer than in the cultured cells (Quievryn and Zhitkovich, 2000). Later in vivo studies by Lai (2016) indicated an even more substantially slower repair. In rats exposed to 2.5 mg/m^3^ formaldehyde for 28 days, 87% of the exposure-induced DPX were retained in the nasal tissues at 1-week postexposure.

Second, Subramaniam et al. (2007) reexamined the Casanova et al. (1994) data for their PBPK modeling and concluded that the experimental results in Casanova et al. (1994) were consistent with the smaller experimental value of kloss indicated by the Quievryn and Zhitkovich (2000) data. Subramaniam et al. (2007) found a significantly decreased (≈ 40%) level of DPXs in the high tumor regions of preexposed animals relative to naive animals at 6 and 15 ppm. This was accompanied by a substantial increase in weight of the tissues dissected from those regions indicating a thickening of the tissues as is to be expected from metaplastic transformation of normal tissue to the squamous type due to formaldehyde toxicity. However, after testing the outcome of changing the tissue thickness in the PBPK model for DPXs, it was apparent to these authors that such a change alone could not account for the dramatic reduction in DPX levels after preexposure, even with the higher value of kloss used by Conolly et al. (2000). Because Vmax was found to be very sensitive to tissue thickness (as also noted by others; (Klein et al., 2011; Georgieva et al., 2003; Conolly et al., 2000)), Subramaniam et al. (2007) increased the value of Vmax with exposure (in a tissue region- and dose-specific manner) and found that it was possible to explain the naïve versus preexposed data of Casanova et al. (1994) with the 7-fold lower value of kloss. This was consistent with the hypothesis of either an induction in the activity of enzymes that remove formaldehyde (aldehyde- and formaldehyde dehydrogenase) or other changes in the biochemical properties of highly exposed tissue.

Third, the value for kloss used by Conolly et al. (2000) was inferred indirectly from measurements made at only two time points where significant changes in the tissue had occurred. On account of these reasons, Subramaniam et al. (2007) considered the use of the lower value for kloss from in vitro observations to be more appropriate. The same lower value of kloss was also used by Georgieva et al. (2003). Consequently, Subramaniam et al. (2007) reimplemented and reoptimized the Conolly et al. (2000) model with this modification and obtained a good fit to the acute DPX data. The reimplemented model is used in this assessment (see Table D-34 for DPX concentrations predicted by the model). Both models provide good similar fits to the DPX data gathered from different regions of the nose immediately after single 3.0-hour and 6.0-hour acute exposures.

Table D-34 Comparison of (Conolly et al., 2000) and (Subramaniam et al., 2007) DPX concentrations, averaged over 1 week (pmol/mm^3^)

Conolly | | | | | | Subramaniam
Flux Bin | 0.7 ppm | 2 ppm | 6 ppm | 10 ppm | 15 ppm | 0.7 ppm | 2 ppm | 6 ppm | 10 ppm | 15 ppm
1 | 8.08E-05 | 2.35E-04 | 7.26E-04 | 1.24E-03 | 1.96E-03 | 3.35E-04 | 9.74E-04 | 3.02E-03 | 5.17E-03 | 8.19E-03
2 | 3.07E-04 | 9.22E-04 | 3.17E-03 | 6.12E-03 | 1.16E-02 | 1.27E-03 | 3.83E-03 | 1.33E-02 | 2.58E-02 | 4.96E-02
3 | 5.34E-04 | 1.66E-03 | 6.46E-03 | 1.46E-02 | 3.47E-02 | 2.22E-03 | 6.90E-03 | 2.73E-02 | 6.27E-02 | 1.51E-01
4 | 7.61E-04 | 2.44E-03 | 1.09E-02 | 2.94E-02 | 7.64E-02 | 3.17E-03 | 1.02E-02 | 4.65E-02 | 1.28E-01 | 3.30E-01
5 | 9.99E-04 | 3.32E-03 | 1.74E-02 | 5.35E-02 | 1.31E-01 | 4.16E-03 | 1.39E-02 | 7.51E-02 | 2.33E-01 | 5.56E-01
6 | 1.24E-03 | 4.28E-03 | 2.65E-02 | 8.45E-02 | 1.88E-01 | 5.16E-03 | 1.79E-02 | 1.15E-01 | 3.64E-01 | 7.93E-01
7 | 1.51E-03 | 5.43E-03 | 3.99E-02 | 1.23E-01 | 2.52E-01 | 6.29E-03 | 2.28E-02 | 1.74E-01 | 5.23E-01 | 1.06E+00
8 | 1.75E-03 | 6.53E-03 | 5.44E-02 | 1.57E-01 | 3.07E-01 | 7.28E-03 | 2.75E-02 | 2.36E-01 | 6.66E-01 | 1.28E+00
9 | 2.01E-03 | 7.86E-03 | 7.27E-02 | 1.96E-01 | 3.68E-01 | 8.41E-03 | 3.32E-02 | 3.14E-01 | 8.26E-01 | 1.53E+00
10 | 2.30E-03 | 9.42E-03 | 9.39E-02 | 2.37E-01 | 4.32E-01 | 9.62E-03 | 3.99E-02 | 4.03E-01 | 9.95E-01 | 1.79E+00
11 | 2.59E-03 | 1.11E-02 | 1.15E-01 | 2.76E-01 | 4.93E-01 | 1.08E-02 | 4.72E-02 | 4.92E-01 | 1.16E+00 | 2.04E+00
12 | 2.89E-03 | 1.30E-02 | 1.38E-01 | 3.17E-01 | 5.55E-01 | 1.21E-02 | 5.56E-02 | 5.87E-01 | 1.33E+00 | 2.30E+00
13 | 3.19E-03 | 1.51E-02 | 1.61E-01 | 3.57E-01 | 6.16E-01 | 1.34E-02 | 6.49E-02 | 6.81E-01 | 1.49E+00 | 2.55E+00
14 | 3.50E-03 | 1.75E-02 | 1.84E-01 | 3.97E-01 | 6.76E-01 | 1.47E-02 | 7.52E-02 | 7.75E-01 | 1.65E+00 | 2.80E+00
15 | 3.83E-03 | 2.02E-02 | 2.08E-01 | 4.38E-01 | 7.38E-01 | 1.61E-02 | 8.72E-02 | 8.73E-01 | 1.82E+00 | 3.05E+00
16 | 4.15E-03 | 2.31E-02 | 2.30E-01 | 4.76E-01 | 7.97E-01 | 1.75E-02 | 9.98E-02 | 9.66E-01 | 1.98E+00 | 3.29E+00
17 | 4.53E-03 | 2.67E-02 | 2.56E-01 | 5.20E-01 | 8.63E-01 | 1.91E-02 | 1.16E-01 | 1.07E+00 | 2.16E+00 | 3.56E+00
18 | 4.89E-03 | 3.03E-02 | 2.79E-01 | 5.58E-01 | 9.21E-01 | 2.06E-02 | 1.31E-01 | 1.17E+00 | 2.31E+00 | 3.80E+00
19 | 5.24E-03 | 3.39E-02 | 3.00E-01 | 5.94E-01 | 9.76E-01 | 2.20E-02 | 1.47E-01 | 1.25E+00 | 2.46E+00 | 4.03E+00
20 | 5.75E-03 | 3.97E-02 | 3.31E-01 | 6.46E-01 | 1.05E+00 | 2.42E-02 | 1.72E-01 | 1.38E+00 | 2.68E+00 | 4.35E+00

##### Sensitivity to use of historical controls

Use of historical controls: Conolly et al. (2003) combined the historical controls arising from the entire NTP database of bioassays. Tumor and survival rates in control groups from different NTP studies are known to vary due to genetic drift in animals over time and differences in laboratory procedures, such as diet, housing, and pathological procedures (Rao et al., 1987;Haseman, 1995). In order to minimize extra variability when historical control data are used, the current NTP practice is to limit the historical control data, as far as possible, to studies involving the same route of exposure and to use historical control data from the most recent studies (Peddada and Kissling, 2006).

Bickis and Krewski (1989) analyzed 49 NTP long-term rodent cancer bioassays and found a large difference in determinations of carcinogenicity, depending on the use of historical controls with concurrent control animals. The historical controls used in the CIIT modeling controls came from different rat colonies and from experiments conducted in different laboratories over a wide span of years, so it is clearly problematic to assume that background rates in these historical control animals are the same as those in the concurrent control group. There are considerable differences among the background tumor rates of SCCs in all NTP controls (13/7,684 = 0.0017), NTP inhalation controls (1/4,551 = 0.0002), and concurrent controls (0/341 = 0.0). The rate in all NTP controls is significantly higher than that in NTP inhalation controls (p = 0.01, Fisher’s exact test). Given these differences, the inclusion of any type of historical controls is problematic and is thought to have limited value if these factors are not controlled for (Haseman, 1995).

Influence of historical controls on model calibration and on human model: To investigate the effect of including historical controls in the CIIT model, the analyses in Subramaniam et al. (2007) were conducted by using the following sets of data for controls (the fraction of animals with SCCs is denoted in parentheses): (a) only concurrent controls (0/341), (b) concurrent controls plus all the NTP historical control data used by (Conolly et al., 2003) (13/8,031), (c) concurrent controls plus data from historical controls obtained from NTP inhalation studies (1/4,949) (National Toxicology Program (NTP), 2005).^34^

The results of the evaluation are shown in Table D-35. For these analyses, the same normal cell replication rates and the same relationship, equations D-20 & D-21, between initiated cell and normal cell replication rates as used in Conolly et al. (2003) were used. In all cases, weekly averaged values of DPX concentrations were used. Model fits to the tumor incidence data were similar in all cases to that shown in Figure 5-5 [see Subramaniam et al. (2007) for a more complete discussion]. The biggest influence of the control data was seen to be on the estimated basal mutation rate in rats, µ_Nbasal(rat)_, which, in turn, influences the estimated mutation effect in humans through equation D-22. α_max_ was also seen to be a sensitive parameter and is discussed later. See Subramaniam et al. (2007) for other parameters in the calibration.

Table D-35 Influence of control data in modeling formaldehyde-induced cancer in the F344 rat

Case | A | D | B | E | C | F
Control animals (combined with concurrent controls) | All NTP historical^a^ | All NTP historical^a^ | NTP inhalation historical^a^ | NTP inhalation historical^a^ | Concurrent only^a^ | Concurrent only^a^
Cell replication dose response | J shape | Hockey stick | J shape | Hockey stick | J shape | Hockey stick
Log-likelihood | −1,692.65 | −1,693.68 | −1,493.21 | −1,493.35 | −1,474.29 | −1,474.29
µ_Nbasal_ | 1.87 × 10^–6^ | 2.12 × 10^–6^ | 7.32 × 10^–7^ | 9.32 × 10^–7^ | 0.0 | 0.0
KMU | 1.12 × 10^–7^ | 0.0 | 6.84 × 10^–7^ | 6.18 × 10^–7^ | 1.20 × 10^–6^ | 1.20 × 10^–6^
KMU:µ_Nbasal_ | 0.06 (0.0, 0.40) | 0.0 (0.0, 0.25) | 0.94 (0.26, 6.20) | 0.66 (0.2, 5.20) | ∞ (0.42, ∞) | ∞ (0.41, ∞)
αmax | 0.045 (0.029, 0.045) | 0.045 (0.029, 0.045) | 0.045 (0.026, 0.045) | 0.045 (0.027, 0.045) | 0.045 (0.027, 0.045) | 0.045 (0.027, 0.045)

a Values in parentheses denote lower and upper 90% confidence bounds.

Source: Adapted from Subramaniam et al. (2007).

The ratio KMU:µ_Nbasal_ is of particular interest because extrapolation to human in Conolly et al. (2004) assumed its invariance as given by equation B-15. Now, μ_Nbasal_ in the human is estimated independently by fitting a scaled-up version of the two-stage model to human baseline rates of tumor incidence. Thus, a decrease in the value of μ_Nbasal_ estimated in the rat modeling increases the formaldehyde-induced mutational effect in the human.

The MLE of KMU_rat_:µ_Nbasal(rat)_ is zero in (Conolly et al., 2003). However, in the various cases examined in Subramaniam et al. (2007) it takes a range of values from 0 to 0.9 mm^3^/pmol and undefined (or infinite, when μ_Nbasal_ = 0). The 95% upper confidence bound on this ratio ranges from 0.25–6.2 [these values would be four times larger had the Conolly et al. (2003) DPX concentrations been used] to infinite. Thus, the extrapolation to human risk by using the approach in Conolly et al. (2004) becomes particularly problematic when only concurrent controls are used, because then the mutational contribution to formaldehyde-induced risk in humans becomes unbounded. This issue will be discussed again toward the end of the discussion on historical controls.

It may be noted, however, that absence of tumors in the limited number of concurrent animals does not imply that the calculation will necessarily predict a zero background probability of tumor (i.e., a parameter estimate of μ_Nbasal_ = 0). Nonetheless, when μ_Nbasal_ = 0, an upper bound for μ_Nbasal_ using the concurrent controls could be inferred. Accordingly, the 90% statistical lower confidence bound on the ratio KMU:µ_Nbasal_ is also reported in Table D-35. Such a value would of course provide a [underlined: lower] bound on risk by using this model and, therefore, would not be conservative.

Conolly et al. (2003) estimated KMU to be zero for both their hockey-stick and J-shaped dose-response models for cell replication. However, the estimate for the coefficient KMU [obtained using the solution of Crump et al. (2005)] is zero only for the case of the model with the hockey-stick curve for cell replication and with control data as used by Conolly et al. (2003). It is positive in all other cases and statistically significantly so in all cases in which either NTP inhalation control data or concurrent controls were used. With concurrent controls only and the J-shaped cell replication model, the MLE estimate for KMU (1.2 × 10^–6^) is larger than the statistical upper bound obtained by Conolly et al. (2003) (8.2 × 10^–7^). The estimate would be about 4.2 times larger had the Conolly et al. (2003) DPX model been used.

Influence of historical controls on dose-response curve: Subramaniam et al. (2007) showed that inclusion of historical controls had a strong impact on the tumor probability curve below the range of exposures over which tumors were observed in the formaldehyde bioassays. As shown there, the MLE probabilities for occurrence of a fatal tumor at exposure concentrations below 6 ppm were roughly an order of magnitude higher when [underlined: all] the NTP historical controls were used, compared with MLE probabilities predicted when historical controls were drawn only from [underlined: inhalation] bioassays, and many orders of magnitude higher than MLE probabilities predicted when only concurrent controls were used in the analysis. (Note that this comparison should not be inferred to apply to upper bound risk estimates because there were many fewer concurrent than historical controls, so error bounds could be much larger in the case where concurrent controls were used.)

However, as shown by these authors, model fits to the tumor data in the 6–15 ppm exposure concentration range were qualitatively indifferent to which of these control data sets was used. This observation emphasizes the statistical aspect of the CIIT modeling—that significant interplay among the various adjustable parameters allows the model to achieve a good fit to the tumor incidence data independent of the control data used. On the other hand, the results in Subramaniam et al. (2007) show that changes in the control data affect parameter KMU, resulting in significantly different tumor predictions at lower exposure concentrations. Therefore, the strong influence of using all the NTP historical controls on the low-dose region of the time-to-tumor curves presented in Subramaniam et al. (2007) suggests that large uncertainties may arise in extrapolating to both human and rat (in the low-dose region) from such considerations alone.

A crucial point needs to be noted with regard to the use of inhalation NTP historical controls (i.e., cases B and E) in the two-stage clonal growth modeling. The single relevant tumor in the NTP inhalation studies came from the very first NTP inhalation study, dated 1976, and the animals in this study were from Hazelton Laboratories, whereas the concurrent animals were all from Charles River Laboratories. Similar problems arise with inclusion of several other NTP inhalation studies. As mentioned before, genetic and other time-related variation can lead to different tumor and survival rates, and in general it is recommended that use of historical controls be restricted to the same kind of bioassays and to studies within a 5–7-year span of the concurrent animals (Peddada et al., 2007). Thus, it is problematic to assume that the tumor in the 1976 NTP study is representative of the risk of SCCs in the formaldehyde bioassays. Even if it were appropriate to consider the 1976 study, this leads to the unstable situation in which the only piece of data that might keep the model predictions of human risk bounded is a single tumor found among several thousand rats from NTP bioassays (Crump et al., 2008). In summary, although it can be argued that the rate of SCCs among the controls in the rat bioassay is probably not zero, it is also problematic to assume that this rate can be adequately represented by the background rate in NTP historical controls or even in NTP inhalation historical controls.

Effect of historical controls on modeling inferences regarding mode-of-action: Subramaniam et al. (2007) also examined the contribution of the DPX component (which represents the directly mutagenic potential of formaldehyde in the model) to the calculated tumor probability, choosing for their case study the optimized models that use the NTP inhalation control data. In the range of exposures where tumors were observed (6.0–15.0 ppm), the DPX term was found to be responsible for 58–74% of the added tumor probability. Below 6.0 ppm the estimated DPX contribution was extremely sensitive to whether the hockey-stick shape or J-shaped was used to characterize the dose response for cell replication, and varied between 2% and 80%.

Several formaldehyde risk assessment efforts and papers have argued based on the CIIT BBDR cancer modeling that the direct mutations induced by formaldehyde are relatively irrelevant compared to the importance of cytotoxicity-induced cell proliferation in explaining the observed tumorigenicity in rodent bioassays (Slikker et al., 2004; Conolly et al., 2004; Bogdanffy et al., 1999; Bogdanffy et al., 2001). The results from Subramaniam et al. (2007) in the above paragraph indicate that the CIIT modeling neither supports an inference that cytotoxicity-driven regenerative cell proliferation is the sole driver of formaldehyde-induced carcinogenicity nor an inference that a significant contribution of mutagenicity at lower doses is unlikely.

##### Characterization of uncertainty-variability in cell replication rates

Dose-response for normal cell division rate as used in model: (Monticello et al., 1991;Monticello et al., 1996) used unit length labeling index (ULLI) to quantify cell replication within the respiratory epithelium. ULLI is a ratio between a count of labeled cells and the corresponding length (in millimeters) of basal membrane examined, whereas the per-cell labeling index (LI) is the ratio of labeled cells to all epithelial cells, in this case, along some length of basal membrane and its associated layer of epithelial cells. Monticello et al. (1991); Monticello et al. (1996) published ULLI values averaged over replicate animals for each combination of exposure concentration, exposure time, and nasal site. These values are plotted in Figure D-24.

To use the ULLI data in clonal growth modeling, ULLI needed to be related to LI, and thereby to cell replication rate (α_N_) of normal cells. Conolly et al. (2003) adopted the following procedure in using these values:

1) The injection labeled ULLI data were first normalized by the ratio of the average minipump ULLI for controls to the average injection labeled ULLI for controls.
2) Next, these ULLI average values were weighted by the exposure times in (Monticello et al., 1991; Monticello et al., 1996) and averaged over the nasal sites. Thus, the data were combined into one TWA for each exposure concentration.
3) LI was linearly related to the measured ULLI by using data from a different experiment (Monticello et al., 1990) where both quantities had been measured for two sites in the nose.
4) Cell replication rates of normal cells (α_N_) were then calculated as α_N_ = (−0.5/t)log(1 − LI) (Moolgavkar and Luebeck, 1992), where LI is the labeling index and t is the period of labeling.
5) This was repeated for each exposure concentration of formaldehyde, resulting in one value of α_N_ for each exposure concentration.
6) Correspondingly, for a given exposure concentration, the steady-state formaldehyde flux into tissue, computed by CFD modeling, was averaged over all nasal sites. Thus, the α_N_(flux) constructed by Conolly et al. (2003) consisted of a single α_N_ and a single average flux for each of six exposures.

This yielded a J-shaped dose-response curve for cell replication (when viewed on a nontransformed scale for α_N_), as shown in Figure D-25 for the full range of flux values used in their modeling. The authors also considered a hockey-stick threshold representation of their J-shaped curve for α_N_ in order to make a health-protective choice, and the differences between the two can be seen from the insets in the Figure. In these curves, the cell replication rate is less than or the same as the baseline cell replication rate at low formaldehyde flux values. The shape of the dose-response curve for cell replication as characterized in Conolly et al. (2003) is seen as representing regenerative cell proliferation secondary to the cytotoxicity of formaldehyde (Conolly, 2002). Considerable uncertainty and variability, both quantitative and qualitative, exist in the use and interpretation of these labeling data for characterizing a dose response for cell replication rates. The primary issues are discussed here. Unlike the preceding sections, these have largely not been published elsewhere, so more details are provided.

Figure D-24 ULLI data for pulse and continuous labeling studies

Note: Data are from pulse labeling study, left-hand side, at 1–42 days of exposure and from the continuous-labeling study, right-hand side, at 13–78 weeks of exposure for five nasal sites ALM, AMS, MMT, PLM, and posterior mid septum [PMS]). Within each graph, lines with more breaks correspond to shorter exposure times. Data source: (Monticello et al., 1991; Monticello et al., 1996).

###### Time variability in labeling data

[underlined: Short-time exposure effects on cell replication]: Figure D-24 shows the site and time variation in the raw unit-length labeling index (ULLI) data for 1 day to 78 weeks of exposure duration. The dose-response for ULLI is quite different between the “early time” (left panel) and “later time” (right panel) and these early time effects may be quite important to the cancer modeling. At the earliest times in the left panel, the data show an increased trend in labeling at 2 ppm for the sites anterior lateral meatus (ALM), anterior medial septum (AMS), posterior lateral meatus (PLM), and medial maxilloturbinate (MMT) relative to control.

The early times would be important if, say, repeated episodic exposures were considered, where adequate time has not elapsed for adaptive effects to take place. Such an exposure scenario may be the norm in the human context. In the cancer modeling in Conolly et al. (2003), because the LI was weighted by exposure time, the contribution of the early time labeling data is minimized.

[underlined: Uncertainty due to combining pulse and continuous labeled data][underlined: :] The formula used for obtaining α_N_ from LI in Conolly et al. (2003) was due to Moolgavkar and Luebeck (1992) who derived this formula for continuous LI, cautioning that it is not applicable for pulse labeled data because it is unclear as to how long the (pulsed) label is available in the tissue. However, Conolly et al. (2003) applied this formula to the injection (pulse) labeled data also. Such an application is problematic because it takes about 4-8 hours of labeling for the relation between labeling index and the rate of cell proliferation to stabilize (see for example the data in Novak and Fedoroff (1996)). Therefore, there is concern that the 2-hour pulse labeled data will represent the pool of cells in S-phase rather than inform the rate at which cells are recruited to that pool. Furthermore (and perhaps on account of this), the baseline values of α_N_ calculated by Conolly et al. (2003) from both data sets differ considerably. Consequently, it is not evident that adjustment by a multiplier can produce a reasonably correct estimate of labeling index and cell division rate for the pulse-label data of Monticello et al. (1991) that is comparable to those from the continuous-label data of Monticello et al. (1996), especially not for purposes of combining and jointly analyzing the resulting estimates of cell proliferation rates. As such, we are not aware of any reasonable manner to derive cell replication rates from these pulse data without acquisition of data at additional time points. Because of these problems in incorporating the pulse-labeled data, further quantitative analysis of cell replication rates is restricted in this document to the continuous labeled data (Monticello et al., 1996), which do not include measurements made before 13 weeks of exposure.

###### Site and time variability in derived cell replication rate

In the remainder of this section, the factors that are considered in order to represent the uncertainty and variability in the cell replication data when developing alternate dose-response curves for α_N_(flux) will be elaborated.

The ULLI data for individual animals were provided by CIIT, which were transformed to LI values using the linear relationship from step 3 above. For these replicate data, cell replication rates of normal cells (α_N_) were then calculated as α_N_ = (−0.5/t)log(1 − LI) as in Step 4. Figure D-25 (adapted from (Subramaniam et al., 2008)) shows the variability in α_N_ due to replicated animals, exposure times, and nasal sites in the continuous labeled data obtained by Monticello et al. (1996). In this figure, log α_N_ versus site-specific flux are plotted for six sites and four exposure times for four to six replicate animals in each case. (The mean ULLI over these replicates were shown in Figure D-24 for each site and time as a function of exposure concentration.) It needs to be noted that these nasal sites differ considerably in the number of cells estimated at these locations as shown in Table D-36. Each point in Figure D-25 represents data from a single site for a single animal at a given time. For comparison, the time weighted and site averaged α_N_(flux) in Conolly et al. (2003) is also plotted in this figure at their averaged flux values (filled red circles). For flux >9,340 pmol/mm^2^-hour, Conolly et al. (2003) extrapolated this empirically derived α_N_(flux) by using a scheme discussed in the section on Model Structure and Calibration in Appendix D.2.2. The curves shown connecting the filled circles in the figure represent their linear interpolation (long dashes) among the six points. Their linear extrapolation for flux value >9,340 pmol/mm^2^-hour is also shown (short dashes). Note that the linear interpolation and extrapolation are shown transformed to a logarithmic scale in this plot.

As discussed, the raw labeling data plotted in Figure D-24 indicates considerable temporal variability. In Figure D-26 & Figure D-27, fitted dose-response curves showing log_10_(α_N_) versus flux with simultaneous confidence limits separately for each time point for two of the largest sites in Table D-36 (ALM and PLM) are plotted for the continuous labeled data. Note that flux levels are different at each site. Simple polynomial models in flux (as a continuous predictor), with time included as a factor (i.e., a class or indicator variable, τ_i_ representing the effect of the i^th^ time) were used as follows:

log (α_N_) = a + b × flux + c × flux^2^ + d × flux^3^ + τ_i_ (D-23)

Figure D-25 Logarithm of normal cell replication rate α_N_ versus formaldehyde flux (in units of pmol/mm^2^-hour) for the F344 rat nasal epithelium

Note: Values were derived from continuous unit length labeled data obtained by Monticello et al. (1996) for four to six individual animals at all six nasal sites (legend, sites as denoted in original paper) and four exposure durations (13, 26, 52, 78 weeks). Each point represents a measurement for one rat, at one nasal site, and at a given exposure time. Filled red circles: α_N_(flux) used in Conolly et al. (2003) plotted at their averaged flux values (see text for details). Long dashed red lines: their linear interpolation among points. Short dashed red line: their linear extrapolation for flux values 9,340 to 39,300 pmol/mm^2^-hr (full extrapolation not shown; see Figure D-23 for full range). Linear interpolation/extrapolation is shown with y-axis transformed to logarithmic scale. Source: Subramaniam et al. (2008).

Table D-36 Variation in number of cells across nasal sites in the F344 rat

Nasal site | No. of cells
Anterior lateral meatus | 976,000
Posterior lateral meatus | 508,000
Anterior mid septum | 184,000
Posterior mid septum | 190,000
Anterior dorsal septum | 128,000
Anterior medial maxilloturbinate | 104,000

Note: Mean number of cells in each side of the nose of control animals.

Source: Monticello et al. (1996).

Figure D-26 Logarithm of normal cell replication rate versus formaldehyde flux with simultaneous confidence limits for the ALM

Source: Subramaniam et al. (2008).

Figure D-27 Logarithm of normal cell replication rate versus formaldehyde flux with simultaneous confidence limits for the PLM

Source: Subramaniam et al. (2008).

The variability considered is that among animals and any measurement error as well as any other design-related components of error. Simultaneous 95% confidence limits for log(α_N_) were produced using Scheffe’s method (Snedecor and Cochran, 1980). These 95% confidence limits span a range of 0.96 in log10(α_N_), or nearly a 10-fold range in median α_N_. There is additional dispersion in these data that does not appear in Figures D-25 to D-27 for α_N_, derived using the mean value of ULLI:LI; due to variation in the number of cells per mm basement membrane, the ratio of ULLI:LI had a spread of approximately ±25% (0.45 to 0.71, mean 0.60) among the eight observations considered in Monticello et al. (1990). Thus:

1) As suggested by Table D-36, and Figures D-26 and D-27, the shape of α_N_(flux) in Conolly et al. (2003) is likely to be very sensitive to how α_N_ is weighted and averaged over site and time.
2) Averaging of sites could significantly affect model calibration because of substantial nonlinearity in model dependence on α_N_ at the 10 and 15 ppm doses associated with high cancer incidence.
3) Monticello et al. (1996) found a high correlation between tumor rate and the ULLI weighted by the number of cells at a site. Therefore, considering these factors while regressing α_N_ against tissue dose would be important in the context of site differences in tumor response.
4) Histologic changes and thickening occur in the nasal epithelium over time in the higher dose groups (Morgan, 1997), factors that are likely to affect estimates of local formaldehyde flux, uptake, and replication rates (Subramaniam et al., 2008).

It is clear from Figures D-25, D-26 and D-27 that the time dependence in cell replication is significant. It would also be useful to examine if this time dependence affects the results of the time-to-tumor modeling and if early temporal changes in replication rate are important to consider because of the generally cumulative nature of cancer risk. The time window over which formaldehyde-induced cancer risk is most influenced is not known, but the time weighting used by Conolly et al. (2003) assigns a relatively low weight to labeling observed at early times compared with those observed at later time points. Finally, initiated cells are likely to be replicating at higher rates than normal cells as evidenced in several studies on premalignant lesions (Rotstein et al., 1986; Dragan et al., 1995; Coste et al., 1996). Therefore, LI data as an estimator of normal cell replication rate would be most reliable at early times when the mix of cells sampled include fewer preneoplastic or neoplastic cells.

Given the above uncertainties and variability not characterized in CIIT (CIIT, 1999) or in Conolly et al. (2003), it is clear that many alternatives can be developed for the dose-response for cell replication [α_N_(flux)], including curves consistent with a monotonically increasing trend (also see discussion of the cell replication data from Meng et al. (2010) surrounding Figure D-42). It is important to examine whether additional dose-response curves that fit the cell replication data reasonably well have an impact on estimated risk. Such sensitivity analyses are carried out in the sections that follow.

###### Alternate dose-response curves for cell replication

In conjunction with the other uncertainties, mainly the use of control data and alternative model structures for initiated cell kinetics, the number of plausible clonal growth models to be exercised soon require a prohibitively large investment of time. Therefore, detailed analyses were restricted to a select set of biologically plausible choices of curves for α_N_(flux), which would allow the identification of a range of plausible risk estimates (MLEs and statistical bounds).

Six alternative equations for α_N_ were developed by regression analysis of the Monticello et al. (1996) ULLI data. The replicate data corresponding to the summary data presented in this paper were kindly provided to EPA by CIIT for further analyses. In each of these equations, α_N_ is expressed as a function of formaldehyde flux to nasal tissue (pmol/mm^2^-hour) and, in the case of equation D-29 that explored time-dependence, the duration of exposure to formaldehyde in weeks. All the graphs use flux/10,000 for the x-axis, and the y-axis expresses log_10_ α_N_.

One source of uncertainty in the cell replication dose response in Conolly et al. (2003) is the large value of α_max_ (the cell replication rate corresponding to the upper end of the flux range at 15 ppm exposure) in the upward extrapolation from the empirically determined α_N_(flux) (see Figure D-23 and surrounding text). The optimal value of α_max_, indicated by the thick short arrow in Figure D-23, was found by Conolly et al. (2003) to be 0.0435 hour^–1^. As noted by the authors, an argument in support of this value is that it corresponds to the inverse of the fastest cell cycle times found in the literature. Because the model treats the induced replication rates as being time invariant, this means that cells in the high-flux region(s) divide at the highest cell turnover rate ever observed throughout most of an animal’s life. This does not seem to be biologically plausible (Subramaniam et al., 2008).

Our analysis found that a 20% increase or decrease in the estimated value for α_max_ degraded the fit to the tumor incidence data considerably. Because of the interplay among the parameters estimated by optimization, this sensitivity of the model to α_max_ indicates that it is necessary to examine if other plausible values of α_max_ are also indicated by the data and to what extent low dose estimates of risk are influenced by the uncertainty in its value. The need for such an analysis is also indicated by Figure D-23. The value of α_max_ (log_10_α_max_ = −1.37) in Conolly et al. (2003) is roughly an order of magnitude greater than the highest empirical values of α_N_(flux) derived from the observed labeling index data corresponding to the flux denoted by the long arrow in Figure D-23. If the data pooled over all sites and times are to be used for α_N_(flux), then, based solely on the trend in α_N_(flux) in Figure D-23, it appears unlikely that α_N_(flux) could increase up to this value of α_max_. Visually, these empirically derived data in Figure D-25 collectively suggest that α_N_ versus flux could be leveling off rather than increasing 10-fold. Therefore, as an alternative to the approach taken in Conolly et al. (2003) of estimating α_max_ via likelihood optimization against the tumor data, regressions of the empirical cell replication data in Figure D-25 were used to extrapolate α_N_(flux) outside the range of observation (recognizing the uncertainty and model dependence that still results from extrapolating well outside the range of observed data).

In fitting dose-response curves to the cell replication data, a functional form was used that was flexible to allow a variety of monotonic and nonmonotonic shapes, with a parameter that determined the asymptotic behavior of the dose-response function. This allowed the extrapolation of α_N_ (flux) to higher flux levels by only relying on the empirical cell replication data. Then, there is no need for an adjustable parameter to be estimated by fitting to the tumor data. However, the plausible asymptotes obtained in this manner spanned a large range. In one case below, the asymptote suggested by the fit to the empirical cell replication data was judged to be abnormally high. In this case, the α_N_ versus flux curve was followed until the biological maximum of α_max_ [as given in Conolly et al. (2003)] was reached.

In three of the six regression models below, the data were restricted to the earliest exposure time (13 weeks) in Monticello et al. (1996) for which the cell proliferation rate (α_N_) could be calculated. The interest in using only the 13-week exposure time also arises from observations (Monticello et al., 1991; Monticello et al., 1996) that at later times there were more frequent and severe histologic changes, which may have altered formaldehyde uptake and cell proliferation response. Consequently, given that the data in Monticello et al. (1991) for times earlier than 13 weeks could not be used as explained in the Section in Appendix D.2.2 on “uncertainty due to combining pulse and continuous labeled data,” the 13-week responses might better represent proliferation rates for use in a two-stage model of the cancer process than the rest of the Monticello et al. (1996) data.

Second, the LI data showed considerable variation among nasal sites, which may be related to the variation in tumor response among sites. Because the cell replication dose-response curves used in the cancer model represent all of the sites, it was attempted to include this variation by weighting the regression by the relative cell populations at risk at each of the sites. This was carried out for some of the models as stated below.

Finally, in one of the regression models, derived from fitting to all of the Monticello et al. (1996) ULLI data, time-dependence of α_N_ was considered by using weeks of exposure as a covariate. In this model, time was a regression (continuous) predictor, not a class variable, and its coefficient represents the change in log_10_ α_N_ per week of exposure.

The following regression models for α_N_ versus flux, denoted in the equations below as N1–N6 and shown in Figures D-28 to D-33, as well as the hockey-stick and J-shaped curves used by Conolly et al. (2003), shown in Figures D-23, were next used as inputs to the clonal growth model for cancer:

Figure D-28 Various dose-response models of normal cell replication rate; N1

Note: See text for definitions of N1–N6. N1: Quadratic; monotone increasing in flux, derived from fit to all of the Monticello et al. (1996) ULLI data.

Figure D-29 Various dose-response models of normal cell replication rate; N2

Note: See text for definitions of N1–N6. N2: Linear-quadratic; decreasing in flux for small values of flux, derived from fit to all of the Monticello et al. (1996) ULLI data.

Figure D-30 Various dose-response models of normal cell replication rate; N3

Note: See text for definitions of N1–N6. N3: Linear-quadratic; decreasing in flux for small values of flux, derived from fit to the 13-week Monticello et al. (1996) ULLI data, using average flux over all sites for a given ppm exposure and weighting regression by estimates of the numbers of cells at each of five sites.

Figure D-31 Various dose-response models of normal cell replication rate; N4

Note: See text for definitions of N1–N6. N4: Quadratic; monotone increasing in flux, derived from unweighted fit to 13-week Monticello et al. (1996) ULLI data.

Figure D-32 Various dose-response models of normal cell replication rate; N5

Note: See text for definitions of N1–N6. N5: Linear-quadratic-cubic; initially increasing slightly with increasing flux, then decreasing slightly, and finally increasing, derived from fit to 13-week Monticello et al. (1996) ULLI data, using average flux over all sites for a given ppm exposure and weighting regression by estimates of the numbers of cells at each of five sites.

Figure D-33 Various dose-response models of normal cell replication rate; N6

Note: See text for definitions of N1–N6. N6: Linear-quadratic-cubic; initially increasing slightly with increasing flux, then decreasing slightly, and finally increasing, derived from fit to all Monticello et al. (1996) ULLI data, using weeks of exposure as a covariate. In this model, time was a regression (continuous) predictor, not a class variable, and its coefficient represents the decrease in log_10_ α_N_ per week of exposure time.

[underlined: N1]: Quadratic; monotone increasing in flux, derived from fit to all of the Monticello et al. (1996) ULLI data.

α_N_ = Exp {− 2.015 − 6.513 × Exp [− (6.735 × 10^− 4^ × flux)^2^]} (D-24)

[underlined: N2]: Linear-quadratic; decreasing in flux for small values of flux, derived from fit to all of the Monticello et al. (1996) ULLI data.

α_N_ = Exp {− 5.906 − 2.272 × Exp [2.188 × 10^− 4^ × flux − (2.162 × 10^− 4^ × flux)^2^]} (D-25)

[underlined: N3]: Linear-quadratic; decreasing in flux for small values of flux, derived from fit to the 13-week Monticello et al. (1996) ULLI data, using average flux over all sites for a given ppm exposure and weighting regression by estimates of the numbers of cells at each of five sites.

α_N_ = Exp {− 5.274 − 2.792 × Exp [1.407 × 10^− 4^ × flux − (1.986 × 10^− 4^ × flux)^2^]} (D-26)

[underlined: N4]: Quadratic; monotone increasing in flux, derived from unweighted fit to 13-week Monticello et al. (1996) ULLI data.

α_N_ = Exp {− 3.858 − 4.809 × Exp [− (9.293 × 10^− 5^ × flux)^2^]} (D-27)

[underlined: N5]: Linear-quadratic-cubic; initially increasing slightly with increasing flux, then decreasing slightly, and finally increasing, derived from fit to 13-week Monticello et al. (1996) ULLI data, using average flux over all sites for a given ppm exposure and weighting regression by estimates of the numbers of cells at each of five sites.

α_N_ = Exp {− 5.488 − 2.755 × Exp [− 7.808 × 10^− 5^ × flux + (2.349 × 10^− 4^ × flux)^2^ − (2 . 166 × 1 0^- 4^ × f l u x)^3^]} (D-28)

[underlined: N6]: Linear-quadratic-cubic; initially increasing slightly with increasing flux, then decreasing slightly, and finally increasing, derived from fit to all Monticello et al. (1996) ULLI data, using weeks of exposure as a covariate. In this model, time was a regression (continuous) predictor, not a class variable, and its coefficient represents the decrease in log_10_ α_N_ per week of exposure time.

α_N_ = Exp {7.785 × 10^− 3^ × ( weeks ) − 5.722 − 2.501 × Exp [1.103 × 10^− 4^ ×) flux) ((− (7.223 × 10^− 5^ × flux)^2^ − (1.575 × 10^− 4^ × flux)^3^]} (D-29)

##### Uncertainty in model specification of kinetics of initiated cells

###### Biological implications of assumptions in Conolly et al. (2003)

The results of a two-stage MVK model are extremely sensitive to the values for initiated cell division (α_I_) and death (β_I_) rates, particularly in the case of a sharply rising dose-response curve as observed of formaldehyde. The pool of cells used for obtaining the available LI data (Monticello et al., 1991; Monticello et al., 1996) consists of largely normal cells with perhaps increasing numbers of initiated cells at higher exposure concentrations. As such there is no way of inferring the division rates of initiated cells in the nasal epithelium, either spontaneous (baseline) or induced by exposure to formaldehyde, from the available empirical data. Conolly et al. (2003) considered α_I_(flux) as a function of α_N_(flux) as given by equation D-20. As shown in Figure D-23, α_I_ is estimated in Conolly et al. (2003) to be very similar to α_N_, and a J- or hockey-shaped dose-response curve for α_N_(flux) necessarily results in a J or hockey shape for α_I_(flux).

The J shape for the TWA α_N_(flux) in Conolly et al. (2003) could plausibly be explained, as suggested by the examples in Conolly and Lutz (2004), by a mathematical superposition of dose-response curves describing the effects of the inhibition of cell replication by the formation of DPXs (Heck and Casanova, 1999) and cytotoxicity-induced regenerative replication (Conolly, 2002). However, as explained earlier, there is considerable uncertainty and variability, both qualitative and quantitative, in the interpretation of the LI data and in the derivation of normal cell replication rates from the ULLI data. While the time-weighted averaged (TWA) values of ULLI indicate a J-shaped dose response for some sites, this is not consistently the case for all exposure times and sites. It is not clear why mechanisms that might explain a J-shaped or hockey-stick dose response for normal cell replication should be expected to prevail also for initiated cells.

The next critical assumption in Conolly et al. (2003) was that made for β_I_ (the death rate of initiated cells), namely, β_I_(flux) = α_N_(flux) (equation D-21). No biological justification for this assumed relationship was provided by the authors.

There are no data to evaluate the strength of these assumptions, so Subramaniam et al. (2008) studied the plausibility of various inferences that arise as a result of these assumptions. These inferences are briefly listed here.

- For flux <27,975 pmol/mm^2^-hour, α_I_ > α_N_ (see Figure D-23). Qualitatively, this concept of a growth advantage is in line with data on epithelial and other tissue types with or without exposure to specific chemicals.
- For higher flux levels in Figure D-23, the model indicates α_I_ < α_N_. There are no data to shed further light on this inference.
- At these higher flux levels, initiated cells in the model die at a faster rate than they divide, indicating the extinction of initiated cell clones in regions subject to these flux levels. There are no data indicating formaldehyde to have this effect.

In evaluating these inferences, Subramaniam et al. (2008) point to various data that indicate that initiated cells represent distinctly different cell populations from that of normal cells with regard to proliferation response (Schulte-Hermann et al., 1997; Dragan et al., 1995; Coste et al., 1996; Ceder et al., 2007b; Bull, 2000), have excess capacity to clear formaldehyde and, in general, are considerably more resistant to cytotoxicity, and may already have altered cell cycle control. The resistance to toxicity is manifested variably as decreased ability of the toxicant to induce cell death or to inhibit cell proliferation compared to corresponding effects in normal cells. Therefore, the influence of formaldehyde on apoptosis likely differs between normal and initiated cells.

As concluded in Subramaniam et al. (2008), taken together, there is much data to suggest that inferring α_I_ < α_N_ at cytotoxic formaldehyde flux levels is problematic and that death rates of initiated cells are likely to be very different from those of normal cells.

In the absence of data to indicate that equations D-20 and D-21 are biologically reasonable approaches to link the kinetics of initiated cells with those of normal cells, alternate model structures other than those represented by these relationships considered by Conolly et al. (2003) were explored, given that the two-stage model is extremely sensitive to α_I_ and β_I_. Only alternate model structures that provided a good fit to the time-to-tumor data were considered.

###### Plausible alternative assumptions for αI and βI

Therefore, in the additional sensitivity analysis presented here:

a) initiated cell kinetics are considered to be independent of normal cells, and
b) initiated cell replication dose response cannot take a J shape; this is motivated by the consideration that lower-than-baseline turnover rate represents an increased amount of DNA repair taking place, which may not be consistent with impaired DNA repair in initiated cells.

Thus, two alternatives were considered to equations D-20 for α_I_ (flux):

α_I_ = γ_1_ × [1 + exp (γ_2_ / γ_3_)] / {1 + exp [− (flux − γ_2_) / γ_3_]} (D-30)

α_I_ = max [α_I_ ( I 1 ) , α_NBasal_] (D-31)

Here γ_1_, γ_2_, and γ_3_ are parameters estimated by fitting the cancer model to the rat bioassay data. In equation D-30, α_I_ increases monotonically with flux from a background level of γ_1_ asymptotically up to a maximum value of γ_1_ × [1 + Exp(γ_2_/γ_3_)]. The choice of this functional form in was considered in order to be parsimonious while at the same time allowing for a flexible shape to the dose-response curve. The sigmoidal curve allows for the possibility of a slow rise in the curve at low dose and an asymptote.

Equation D-31 is a modification of equation D-30 that restricts the rate of division of initiated cells to be at least as large as the spontaneous division rate of unexposed normal cells. There is evidence to suggest (e.g., in the case of liver foci) that initiated cells have a growth advantage over normal cells, with or without exposure to specific chemicals (Schulte-Hermann et al., 1999; Grasl-Kraupp et al., 2000; Dragan et al., 1995; Coste et al., 1996; Ceder et al., 2007a).

In addition, in most runs, an upper bound (α_high_) is selected for both α_N_ and α_I_. This value is assumed to represent the largest biologically plausible rate of cell division. Following Conolly et al. (2003), in most cases α_high_ is set equal to 0.045 hours^–1^. If a value of α_I_ or α_N_ computed using one of the above formulas exceeded α_high_, the value of α_high_ was used in the computation rather than the value obtained by using the formula.

As noted above, Conolly et al. (2003) set the rate of death for intermediate cells, β_I_, equal to the division rate of normal cells, β_I_ = α_N_. On the other hand, apoptotic rates and cell proliferation rates are thought to be coupled (Schulte-Hermann et al., 1999; Moolgavkar, 1994), so that death rates of initiated cells would rise concomitantly with an increase in their division rates (Schulte-,Hermann et al., 1999; Grasl-Kraupp et al., 2000). Therefore, as an alternative to the Conolly et al. (2003) formulation, it is assumed that the death rate of intermediate cells is proportional to the division rate of intermediate cells.

β_I_ = K_β_ × α_I_ (D-32)

where the constant of proportionality, κ_β_, is an additional parameter to be estimated by optimization against the tumor incidence data. Such an assumption has also been made by other authors (Moolgavkar et al., 1993; Luebeck et al., 1995; Luebeck et al., 2000).

###### Results of sensitivity analyses on αN, α I, and βI

The number of models that might be constructed if all the possibilities listed above for α_N_, α_I_, and β_I_ are to be tried in a systematic manner clearly become exponential and daunting. (Optimally, it would have been desirable to elucidate the role of a specific modification while keeping others unchanged to determine risk.) Therefore, in order to carry out a viable sensitivity analysis while at the same time examining the plausible range of risks resulting from variations in parameters and model structures, various uncertainties were combined in any given simulation. By using the constraints described above (equations D-24 through D-32) for α_I_, β_I_, and α_N_, 19 models were obtained that provided similarly good fits to the time-to-tumor data (which in some cases contained only five dose groups).

However, for many of these models, the optimal α_I_(flux) displayed a threshold in flux even when the model used for α_N_(flux) was a monotonic increasing curve without a threshold (i.e., model N4 for α_N_ in Figure D-31). Indeed, if a thresholded dose-response curve was plausible for α_I_ based on arguments of cytotoxicity, then a threshold is all the more plausible for α_N_, and such models are removed from consideration.

Secondly, the basal value of α_I_ was required to be at least as large as the basal value of α_N_. Another constraint was placed on the baseline initiated cell replication rate. In the absence of formaldehyde exposure, α_I_ was not allowed to be greater than two or four times α_N_, even if such models described the tumor data, including the control data, very well. There are some data that suggest that baseline initiated cells have a small growth advantage over normal cells, so a huge advantage was thought to be biologically less plausible.

Finally, because most of the SCCs in the rat bioassays occurred in rats exposed to the highest formaldehyde concentration (15 ppm), the data from this exposure level have a big impact on the estimated model parameters. In most runs that incorporated the 15 ppm data, the model appeared, based on inspection of the KM plots, to fit the 15 ppm data quite well but to fit the lower exposure data less well. Because of the high level of necrosis occurring at 15 ppm, it is possible that the data at this exposure may not be particularly relevant to modeling the sharp upward rise in the dose response at 6 ppm. Furthermore, the principal interest is in the predictions of the model at lower levels to which human populations may be exposed. Consequently, in order to improve the fit of the model at lower exposures, some of the alternative models were constructed with the 15 ppm data omitted.

###### Sensitivity of risk estimates for the F344 rat

Figures D-34 and D-35 contain plots of the MLE of additional risk computed for the F344 rat at formaldehyde exposures of 0.001, 0.01, 0.1, and 1 ppm for eight models. Two log-log plots are provided. For those models for which the estimates of additional risk are all positive, the additional risks are plotted (Figure D-34), and, for those for which estimates of additional risk are negative, the negatives of additional risks are plotted (see Figures D-35). Only five dose groups were considered (i.e., 15 ppm data omitted) for models 8, 5, 15, and 16. Figures D-36 and D-37 show the dose-response curves for α_N_ and α_I_ for these eight cases (corresponding to those in Figures D-34 and D-35 respectively). The specification and estimated values of the parameters for these models are provided in Tables D-37 and D-38. The primary results are as follows:

1) Among the models considered, negative values for additional risk can arise only in models in which the dose response for normal cells is J shaped. Thus, all of the models with negative dose responses for risk have J-shaped dose responses for normal cells. However, the converse is not necessarily true as may be noted from model 8. This model has both a positive dose response for risk and a J-shaped dose response for normal cells. In this case, the strong positive increase in response of initiated cells at low dose was sufficient to counteract the negative response of normal cells.
2) For doses below which no tumors were observed, the risk estimates predicted by the different models span a very large range. This result points to large uncertainties in model specification (how to relate the kinetics of normal and initiated cells) as well as in parameter values. As mentioned above, the analysis does not attempt to separate the influence of the different sources of uncertainty, so this range also incorporates the uncertainty arising from the use of different control data and that due to α_max_.

Figure D-34 BBDR models for the rat—models with positive added risk

Note: All four models provide “similar” fits to tumor data (see text).

Figure D-35 BBDR rat models resulting in negative added risk

Note: All four models provide “similar” fits to tumor data (see text).

Figure D-36 Models resulting in positive added rat risk: Dose response for normal and initiated cell replication

Figure D-37 Models resulting in negative added rat risk: Dose response for normal and initiated cell replication

Table D-37 Parameter specifications and estimates for clonal growth models of nasal SCC in the F344 rat using alternative characterization of cell replication and death rates

Parameters | Model 3 | Model 4 | Model 5 | Model 8 | Model 15 | Model 16
Historical controls added to concurrent | Inhalation NTP | Inhalation NTP | Inhalation NTP | Inhalation NTP | Inhalation NTP | Inhalation NTP
Number of dose groups | 6 | 6 | 5 | 5 | 5 | 5
DPX concentration | Subramaniam et al. (2007) | Subramaniam et al. (2007) | Subramaniam et al. (2007) | Subramaniam et al. (2007) | Subramaniam et al. (2007) | Subramaniam et al. (2007)
α_N_ definition | N3 | N6 | N3 | N6 | N4 | N4
α_I_ definition | I2 | I2 | I2 | I1 | I1 | I1
α_high_ | -- | 0.045 | -- | 0.045 | 0.045 | 0.045
β_I_ definition | β_I_ = Κ_β_ × α_I_ | β_I_ = Κ_β_ × α_I_ | β_I_ = Κ_β_ × α_I_ | β_I_ = Κ_β_ × α_I_ | β_I_ = Κ_β_ × α_I_ | β_I_ = Κ_β_ × α_I_
| | | | | γ_1_ ≤ 4 α_NBasal_ | γ_1_ ≤ 2 α_NBasal_
Log-likelihood | −1,495.34 | −1,495.61 | −184.02 | −184.22 | −182.75 | −186.37
µ_NBasal_ | 7.518 × 10^−7^ | 1.664 × 10^−6^ | 8.684 × 10^−7^ | 9.230 × 10^−7^ | 1.037 × 10^−6^ | 1.662 × 10^−7^
KMU | 3.884 × 10^−7^ | 3.471 × 10^−7^ | 0.0 | 0.0 (0.0, 2.093 × 10 ^−6^) | 4.582E-6 (1.8 × 10^6^,1.86 × 10^−5^) | 0.0
KMX (KMU/µ_NBasal_) | 0.5166 | 0.2086 | 0.0 | 0.0 (0.0, 4.696) | 4.420 (1.53, 17.67) | 0.0
D_0_ ^§^ | 214.3 | 199.7 | 261.8 | 254.2 | 423.2 | 245.1
D_0F_ ^§^ | 75.26 | 79.81 | 119.7 | 101.1 | 100.8 | 98.83
γ_1_ | 1.164 × 10^−5^ | 1.006 × 10^−5^ | 3.168 × 10^−5^ | 2.967 × 10^−4^ | 6.888 × 10^−4^ | 3.441 × 10^−4^
γ_2_ | 1427 | 1,591 | 1,825 | 3,223 | 4,652 | 2,818
γ_3_ | 11,944 | 13,017 | 14,207 | 15,989 | 54,334 | 37,896
Κ_β_ | 0.9893 | 0.9848 | 0.9804 | 0.9504 | 1.006 | 0.9660

§ See Subramaniam et al. (2007) for an explanation of the time delay constants D_0_ and D_0F_.

Table D-38 Parameter specifications and estimates for clonal growth models of nasal SCC in the F344 rat using cell replication and death rates as characterized in Conolly et al. (2003)

Parameters | Model 13 | Model 17
Historical controls added to concurrent | All NTP | NO historical controls
Number of dose groups | 6 | 6
DPX concentration | Conolly et al. (2000) | Subramaniam et al. (2007)
α_N_ definition | J shape [TWA, Conolly et al. (2003)] | Hockey [TWA, Conolly et al. (2003)]
α_I_ definition | eq. B-13 | eq. B-13
α_high_ | -- | --
β_I_ definition | β_I_ = α_N_ | β_I_ = α_N_
Log-likelihood | −1,692.68 | −1,474.29
µ_NBasal_ | 1.731 × 10^−6^ | 0.0
KMU | 0.0 | 1.203 × 10^−6^ (1.0 × 10^−6^,1.427 × 10^−6^)
KMX (KMU:µ_NBasal_) | 0.0 | Infinite (0.4097, infinite)
D_0_ ^§^ | 239.5 | 243.13
D_0F_ ^§^ | 66.31 | 68.83
multib | 1.047 | 1.078 × 10^+0^
multic | 1.510 | 3.347
α_max_ | 5.153 × 10^−2^ | 0.045

§ See Subramaniam et al. (2007) for an explanation of the time delay constants D_0_ and D_0F_.

1) At the 10 ppb (0.01 ppm) concentration, MLE risks range from −4.0 × 10^–6^ to +1.3 × 10^–7^. At this dose, models that gave only positive risks resulted in a five orders of magnitude risk range from 1.2 × 10^–12^ to 1.3 × 10^–7^, while narrowing to a four orders of magnitude risk range from 1.2 × 10^–10^ to 1.3 × 10^–6^ at the 0.1 ppm level. This narrowing continues as exposure concentration increases, and the curves coalesce to substantially similar values at 6 ppm and above (not shown). For all these 8 models, the rat added risk at 6.0 ppm ranged from 1.8 × 10^–2^ to 2.1 × 10^–2^.
2) There does not seem to be any systematic effect on additional risk that depends on whether the 15 ppm data are included in the analysis.
3) For all of the models except Models 13 and 17 in Figures D-36 and D-37, the additional risk varies substantially linearly with exposure at low exposures between 0.001 and 1.0 ppm (departing only to a small extent from linearity between 0.1 and 1.0 ppm). Models 13 and 17 show a quadratic dependence; these models employ the TWA J-shaped and hockey stick dose-response curves for α_N_ used in Conolly et al. (2003) and the same equations used by those authors to relate α_I_ and β_I_ to α_N_ (equations D-20 and D-21). However, the control data in Model 17 was different from those used by Conolly et al.; while [underlined: all] NTP controls were added to the concurrent controls in Model 13, only concurrent controls were used in Model 17.

The various model choices presented in Tables D-37 and D-38 all provided equally good fits to the time-to-tumor data although within the context of a significant qualification. It was not possible to simply use the maximized log-likelihood values as a means of comparing the goodness of fit to the tumor incidence data across all these model choices. This is because many of the model choices differed in the number of doses or in the number of control animals that were used, so the fits were compared across such models only visually.

Wherever results from the BBDR modeling are discussed, values of added risk, as opposed to extra risk, are reported. This is purely for convenience in interpretation. Because of the low background incidence, these values are only negligibly different from the corresponding extra risk estimate. The final risk (or unit risk) estimates provided in this document are based on extra risk estimates.

###### Confidence bounds: model uncertainty versus statistical uncertainty

For Models 15 and 17 in Figure D-36, 90% CIs for additional risk were calculated by using the profile-likelihood method. Table D-39 compares the lower and upper confidence bounds for these models for 0.001 ppm, 0.1 ppm (doses well below the range where tumors were observed), and 6 ppm (the lowest dose where tumors were observed) with the MLE risk estimates at these doses. In both cases, these intervals were quite narrow compared with the differences in risk predicted by the different models. This suggests that model uncertainty is of more consequence in the formaldehyde animal model than is statistical uncertainty. We also estimated confidence bounds using the bootstrap method for select models and determined that these estimates were in agreement with the bounds calculated using the profile-likelihood method. These results are not presented here. We return to the calculation of confidence limits when determining points of departure (PODs).

Table D-39 Comparison of statistical confidence bounds on added risk for two models

Dose (ppm) | Model | Lower bound | MLE | Upper bound
0.001 | Model 15 | 4.4 × 10^–9^ | 1.3 × 10^–8^ | 1.6 × 10^–8^
| Model 17 | 1.2 × 10^–14^ | 1.2 × 10^–14^ | 1.3 × 10^–14^
0.1 | Model 15 | 4.5 × 10^–7^ | 1.3 × 10^–6^ | 1.7 × 10^–6^
| Model 17 | 1.2 × 10^–10^ | 1.2 × 10^–10^ | 1.3 × 10^–10^
6 | Model 15 | 1.8 × 10^–2^ | 2.1 × 10^–2^ | 2.3 × 10^–2^
| Model 17 | 1.3 × 10^–2^ | 1.8 × 10^–2^ | 3.0 × 10^–2^

In conclusion, it is demonstrated that the different formaldehyde clonal growth models can fit the data about equally well and still produce considerable variation in additional risk and biological inferences at low exposures.

##### Statistical Methods Used in Evaluation

Parameters of the alternate models shown here were estimated by maximizing the likelihood function defined by the data (Cox and Hinkley, 1974). Such estimates are referred to as maximum likelihood estimates (MLEs). Statistical confidence bounds were computed by using the profile-likelihood method (Crump, 2002; Cox and Hinkley, 1974; Cox and Oakes, 1984). In this approach, an asymptotic 100(1 – α)% upper (lower) statistical confidence bound for a parameter, β, in the animal cancer model is calculated as the largest (smallest) value of β that satisfies

2 [L_max_ − L * ( β )] = x_1 − 2 α_ (D-33)

where L indicates the likelihood of the rat bioassay data, L_max_ is its maximum value, L*(β) is, for a fixed value of β, the maximum value of the log-likelihood with respect to all of the remaining parameters, and x_1–2α_ is the 100(1–2α) percentage point of the chi-square distribution with one degree of freedom. The required bound for a parameter, β, was determined via a numerical search for a value of β that satisfies this equation.

The additional risk is defined as the probability of an animal dying from an SCC by the age of 790 days, in the absence of other competing risks of death, while exposed throughout life to a prescribed constant air concentration of formaldehyde, minus the corresponding probability in an animal not exposed to formaldehyde. The MLE of additional risk is the additional risk computed using MLEs of the model parameters.

The method described above for computing profile-likelihood confidence bounds cannot be used with additional risk because additional risk is not a parameter in the cancer model. Instead, an asymptotic 100(1 – α)% upper (lower) statistical confidence bound for additional risk was computed by finding the parameter values that presented the largest (smallest) value of additional risk, subject to the inequality

2 [L_max_ − L] ≤ x_1 − 2 α_ (D-34)

being satisfied, with the resulting value of additional risk being the required bound. This procedure was implemented through use of penalty functions (Smith and Coit, 1995). For example, the profile upper bound on additional risk was computed by maximizing the “penalized added risk,” defined as (additional risk – penalty), where

penalty = W × {[(L_max_ − L) − x_1 − 2 α_ / 2]^+^}^2^ (D-35)

and []^+^ equals the quantity in the brackets whenever it is positive and zero otherwise. The multiplicative weight, W, was selected by trial and error so that the final solution satisfied the following equation sufficiently well.

2 (L_max_ − L) = x_1 − 2 α_ (D-36)

The computer code was written in Microsoft Excel 2002 SP3 Visual Basic. Either the regular Excel Solver or the Frontline Systems Premium Solver was used to make the required function optimizations. Computation of confidence bounds was highly computationally intensive, and, consequently, confidence bounds were computed only for selected parameters in selected runs. For select cases, the bootstrap method was also used to calculate confidence bounds in order to confirm their accuracy. Values so calculated were found to be in agreement with those calculated by using the likelihood method.

##### Sensitivity Analysis of Conolly et al. (2004) Human Extrapolation Model

###### Uncertainties in the Human Extrapolation Model

Subsequent to the BBDR model for modeling rat cancer, Conolly et al. (2004) developed a corresponding model for humans for the purpose of extrapolating the risk estimated by the rat model to humans. Also, rather than considering only nasal tumors, it is used to predict the risk of all human respiratory tumors. The human model for formaldehyde carcinogenicity (Conolly et al., 2004) is conceptually very similar to the rat model but is not based on any data on human exposure to formaldehyde. Unlike the sensitivity analysis of the rat modeling where a number of issues were examined, a much more restricted analysis will be presented here for the sake of brevity. A more extensive analysis was carried out initially that carried forward several of the rat models in Tables D-37 & D-38 to the human, and the lessons learned from those exercises are in agreement with the more restricted presentation that follows. Table D-40 lists the major uncertainties and assumptions in the human extrapolation model in Conolly et al. (2004).

Table D-40 Summary of evaluation of major assumptions and results in (Conolly et al., 2004)

Assumptions^a^ | Rationale in (Conolly et al., 2004) or (CIIT, 1999) | EPA evaluation | Further elaboration
Cell division rates derived from rat labeling data were assumed applicable to human (except for assuming different fraction of cells with replicative potential). | There are no equivalent LI data for human or guidance for extrapolating cell division rate across species. | Enzymatic metabolism plays a role in mitosis. Therefore, we expect interspecies difference in cell division rate. Basal cell division rates in humans are expected to be much more variable than in laboratory animals. | Subramaniam et al. (2008)
Parameters for enzymatic metabolism of formaldehyde in human PBPK model for DPX concentrations: K_m_ varies by order of magnitude between rat and monkey but is same for monkey and human. V_max_:K_m_ is similar for rat and monkey but 6-fold lower for human. | See “PBPK model for Human DPX…” | See “PBPK model for Human DPX…” | “PBPK model for Human DPX…”; Conolly et al. (2000); Subramaniam et al. (2008); Klein et al. (2011)
Anatomically realistic representation of nasal passages. | Reduces uncertainty (over default calculation carried out by averaging dose over entire nasal surface). | Computer representation pertains to that of one individual (white male adult). There is considerable interindividual variability in nasal anatomy. Susceptible individuals are even more variable. | (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001); (Subramaniam et al., 1998; Subramaniam et al., 2008)
KMU:µ_Nbasal_ is species invariant (used to estimate human). | Human cells are more difficult to transform than rodent, both spontaneously and by exposure to formaldehyde. | µ_Nbasal_ is 0 when concurrent controls or inhalation NTP controls in time frame of concurrent bioassays are used. Leads to infinitely large KMU for human. | Subramaniam et al. (2007); Crump et al. (2009); (Crump et al., 2008).
Conservative assumptions were made. Results are conservative in the face of model uncertainties. | 1) Hockey-stick dose response for α_N_ was included even though TWA indicated J shape.; 2) Overall respiratory tract cancer incidence data for human baseline rates were used.; 3) Risk was evaluated at statistical upper bound of the proportionality parameter relating DPXs to the probability of mutation. | Results in Conolly et al. (2004) are not conservative in the face of model uncertainties: (a) human risk estimates are very sensitive to use of historical controls in the analysis of the animal bioassay, (b) human risk estimates are unboundedly large when concurrent controls are used in rat model, and (c) minor perturbations in model assumptions regarding division and death rates of initiated cells lead to upper bound risks that were more than 1,000-fold greater than the highest estimates in Conolly et al. (2004). | Conolly et al. (2004); Subramaniam et al. (2007); Crump et al. (2009); (Crump et al., 2008).

a Assumptions in this table are in addition to those listed for the BBDR model for the F344 rat.

###### Uncertainties in the PBPK Model for Human DPX Concentrations

Conolly et al. (2000) constructed a PBPK model for the rhesus monkey along similar lines as for the F344 rat, and used the rat and rhesus monkey parameter estimates to develop a model for human DPX concentrations. In the rhesus monkey model, they maintained the same values of k_b_, k_loss_, and k_f_ as in the rat model but optimized the values of Vmax and Km against the rhesus monkey data from Casanova et al. (1994). The resulting human PBPK model used formaldehyde flux estimates predicted by an anatomically realistic CFD modeling of the nasal passages; except for the anatomic reconstruction, there were no other human data used to inform the PBPK model.

For the human, the model used the value of K_m_ estimated by the rhesus monkey model and the epithelial thickness averaged over three regions of the rhesus monkey nose. The maximum rate of metabolism, Vmax, which was estimated independently for the rat and rhesus monkey by fitting to the DPX data available for these species, was then extrapolated to the human by assuming a power law scaling with body weight (BW) (i.e., Vmax = a × BW^b^), and the coefficient “a” and exponent “b” were derived from the independently estimated values of (Vmax)_RAT_ and (Vmax)_MONKEY_. Table D-41 gives the values of Vmax and Km in the Conolly et al. (2000) extrapolation.

Table D-41 Extrapolation of parameters for enzymatic metabolism to the human in Conolly et al. (2000)

Parameter | F344 rat | Rhesus monkey | Human
Vmax (pmol/min-mm^3^) | 1,008.0 | 91.0 | 15.7
Km (pmol/mm^3^) | 70.8 | 6.69 | 6.69

Source: Conolly et al. (2000).

In general, laws for allometric scaling across species, such as how enzymatic metabolic rates vary across organisms, are derived as empirical regression relationships based on data from multiple species and usually multiple sources of data points. For example, West and Brown (2005) demonstrate that metabolic rates scale with mass^3/4^ using data from organisms ranging over 27 orders of magnitude in mass (intracellular up to the largest organisms). In Conolly et al. (2000), the power-law relationship is derived using two data points (F344 rat and rhesus monkey for a single chemical) with log BW as x-axis and Vmax on y-axis. Because such a regression does not have the power to delineate the curvature in the scaling function, the empirical strength of the allometric relationship derived in Conolly et al. (2000) is extremely weak for use in extrapolating from the rat to the human on the basis of body-weight. Furthermore, as noted earlier, V_max_ is highly correlated to K_m_, the value of K_m_ appears to vary substantially between the rat and monkey, and as indicated by the large standard error using multiple methods in Klein et al. (2011), its estimation is fairly uncertain. These observations make the scaling relationship in Conolly et al. (2000) more problematic.

The following observations point to the uncertainty in the values of the parameters Vmax and K_m_ in the Conolly et al. (2000) models for predicting DPXs. First, Km varies by an order of magnitude across the rat and monkey models and considered invariant between the monkey and human models (Conolly et al., 2000). Second, the values in Conolly et al. (2000) for Vmax/Km, the low-dose limit of the rate of enzymatic metabolism, is roughly similar between the rat and monkey but lower by a factor of six in the human.

Another factor that can substantially influence the above extrapolation of DPXs in the human is that Conolly et al. (2000) assumed the tissue to be a well-mixed compartment with regard to formaldehyde interaction with DNA and used the amount of formaldehyde bound to DNA per unit volume of tissue as the DPX dose metric. Considering formaldehyde’s highly reactive nature, the concentrations of formaldehyde and DPX are likely to have a sharp gradient with distance into the nasal mucosa (Georgieva et al., 2003). Cohen Hubal et al. (1997) concluded that the well-mixed assumption is inappropriate at exposure concentrations less than 4 ppm. Furthermore, given the interspecies differences in tissue thickness, there is uncertainty as to whether DPX per unit volume or DPX per unit area of nasal lining is the more appropriate dose metric to be used in the extrapolation. In particular, it may be assumed that the cells at risk for tumor formation are only those in the epithelium and that measured DPX data (in monkeys and rats) are an average over the entire tissue thickness. Because the epithelial DPXs in monkeys (and presumably humans) would then be more greatly “diluted” by lower levels of DPX formation that occur deeper into the tissue than in rats, it could be predicted that the ratio of epithelial to measured DPXs in monkeys and humans would be much higher than the ratio in rats.

On the whole, these observations suggest that human extrapolations of DPX concentrations using the human PBPK model in Conolly et al. (2000) may be highly uncertain.

##### Sensitivity Analysis of Clonal Growth Model for Human Extrapolation

EPA (Crump et al. (2008)) carried out a limited sensitivity analysis of the Conolly et al. (2004) human model. This analysis was limited to evaluating the effect on the human model of the following. These evaluations have been the subject of some debate in the literature and at various conferences (Crump et al., 2009; Conolly et al., 2009).

1) The use of the alternative sets of control data for the rat bioassay data that were considered in the sensitivity analysis of the rat.
2) Minor perturbations in model assumptions regarding the effect of formaldehyde on the division and death rates of initiated cells (α_I_, β_I_).
  - One (of the two) adjustable parameter in the expression for the human α_I_ in Conolly et al. (2004) was determined from the model fit to the rat tumor incidence data while the second parameter was determined from background rates of cancer incidence in the human. Therefore, variations considered in α_I_ were constrained to only those that (a) did not meaningfully degrade the fit of the model to the rat tumor incidence data, as shown in Figure D-41 (i.e. these fits were indistinguishable from those shown in Figure 5-5 of the Toxicological Review), and (b) were in concordance with background rates in the human.
  - Crump et al. (2008). also evaluated these variations with respect to their biological plausibility. The sensitivity analysis on assumed initiated cell kinetics was thought to be particularly important because there were no data to even crudely inform the kinetics of initiated cells for use in the models, even in rats, and the two-stage clonal expansion model is very sensitive to initiated cell kinetics (Gaylor and Zheng, 1996; Crump, 1994a, b).

###### Effect of background rates of nasal tumors in rats on human risk estimates

Crump et al. (2008) quantitatively evaluated the impact of different control groups on estimates of additional human risk as follows:

1) Concurrent controls plus all NTP controls:, the same as used by Conolly et al. (2004);
2) Concurrent controls plus controls from NTP inhalation studies;
3) Only concurrent controls;
4) Each set of control data was applied with both the J shape and hockey-stick models in Conolly et al. (2004) for α_N_(flux) and α_I_(flux) for a total of six analyses.
5) Uncertainties associated with α_N_ or α_I_ are not addressed. Parameters α_max_, multfc, and KMU were estimated in exactly the same manner as in Conolly et al. (2004).

Crump et al. (2008) present the following dose-response predictions of additional risk in humans from constant lifetime exposure to various levels of formaldehyde arising from exercising the above six cases. Their plots are reproduced in Figure D-38, where the corresponding curves based on Conolly et al. (2004) are also shown for comparison.

Figure D-38 Effect of choice of NTP bioassays for historical controls on human risk

Note: Estimates of additional human risk of respiratory cancer by age 80 from lifetime exposure to formaldehyde are obtained by using different control groups of rats.

Source: Crump et al. (2008).

The lowest dotted curve in Figure D-38 represents the highest estimates of human risk developed by Conolly et al. (2004). This resulted from use of the hockey-stick model for cell division rates in conjunction with the statistical upper bound for the parameter KMU. As indicated by the downward block arrows in the figure, their corresponding estimates based on the J-shaped model were all negative for exposures below 1 ppm.

Consider next the solid curves in the figure, which show predicted MLE added risks that were positive and less than 0.5. Crump et al. (2008) next examined the added risk obtained when the MLE estimate of (KMU:µ_basal_) in these cases is replaced by the 95% upper bound of this parameter ratio. The upper bound risk estimates in Conolly et al. (2004) were calculated in a similar manner (but using all NTP historical controls). Except for minor differences, risk estimates corresponding to such an upper bound and using all NTP controls were very similar in the two efforts (Crump et al., 2008; Conolly et al., 2004).

Figure D-38 shows that the choice of controls to include in the rat model can make an enormous difference in estimates of additional human risk. For the J-shaped model for cell replication rate both estimates based on the MLE and those based on the 95% upper bound on KMU:µ_basal_ are negative for formaldehyde exposures below 1 ppm. However, when only concurrent controls are used in the model in Crump et al. (2008), the MLE from the J-shaped model is positive and is more than three orders of magnitude higher than the highest estimates obtained by Conolly et al. (2004). Using only concurrent controls, estimates based on the 95% upper bound on KMU:µ_basal_ are unboundedly large (block arrows at the top of the figure). For the hockey-stick shaped model for cell replication rate, when all NTP controls are used, the estimates based on the MLEs are zero for exposures less than about 0.5 ppm. If only inhalation controls are added, the MLEs are about seven times larger than the Conolly et al. (2004) upper bound estimates, and the estimates based on the 95% upper bound on KMU:µ_basal_ are about 50 times larger than the Conolly et al. (2004) estimates. If only concurrent controls are used, both the MLE estimates and those based on the 95% upper bound on KMU:µ_basal_ are unboundedly large.

###### Alternative assumptions regarding the rate of replication of initiated cells

For the human model, Conolly et al. (2004) made the same assumptions for relating α_I_(flux) and β_I_(flux) to α_N_(flux) as in their rat model (Conolly et al., 2003). That is, these quantities were related by using equations D-20 and D-21. By extending the shape of these curves to humans, the authors’ model brings the cytotoxic action of formaldehyde to bear strongly on the parameterization of the human model as well.

In the sensitivity analyses that follows, calculations similar to that presented in Table 5-40 of the Toxicological Review are continued over a large range of exposure concentrations. In these analyses, Crump et al. (2008) made minor modifications to the assumed division rates of initiated cells in Conolly et al. (2004), while all other aspects of the model and input data were kept unchanged. Two alternatives were considered for each of the hockey-stick and J-shaped models. Figure D-39 shows the hockey-stick model for initiated cells in rats. In the first modification to the hockey-stick model (hockey-stick Mod 1), rather than having a threshold at a flux of 1,240 pmol/m^2^-hour, the division rate increases linearly with increasing flux until the graph intersects the original curve at 4,500 pmol/m^2^-hour, where it then assumes the same value as in the original curve for larger values of flux. The second modification (hockey-stick Mod 2) is similar, except the modified curve intersects the original curve at a flux of 3,000 pmol/m^2^-hour.

Figure D-39 Variations to the hockey-stick model for division rates of initiated cells in rats

Source: Crump et al. (2008).

Figure D-40 shows the rat J-shaped model for initiated cells. In the first modification to this dose response (J-shaped Mod 1), rather than having a J shape, the division rate of initiated cells remains constant at the basal value until the original curve rises above the basal value and has the same value as the original curve for larger values of flux. In the second modification (J-shaped Mod 2), the J shape is retained but somewhat mitigated. In this modification, the division rate initially decreases in a linear manner similar to that of the original model but with a less negative slope until it intersects the original curve at a flux of 1,240 µm/m^2^-hour, where it then follows the original curve for higher values of flux.

Figure D-40 Variations to the J-shaped model for division rates of initiated cells in rats

Source: Crump et al. (2008).

Because the first constraint on the variation in α_I_ was in concordance with the rat time-to-tumor incidence data, Crump et al. (2008) applied each of the modified models in Figures D-39 and D-40 to the version of the formaldehyde models in Subramaniam et al. (2007) that employed all NTP controls and the hockey-stick curve for α_N_. These authors restricted their analysis to this case because their stated purpose was only a sensitivity analysis as opposed to developing alternate credible risk estimates. Figure D-41 reproduces [from Crump et al. (2008)] curves of the cumulative probability of a rat dying from a nasal SCC by a given age for bioassay exposure groups of 6, 10, and 15 ppm. For comparison purposes, the corresponding KM (nonparametric) estimates of the probability of death from a nasal tumor are also shown. Three sets of probabilities are graphed: the original unmodified one and the ones obtained by using hockey-stick Mod 1 and Mod 2. Crump et al. (2008) state that the changes in the tumor probability resulting from these modifications are so slight that the three models cannot be readily distinguished in this graph.^35^ Thus, the modifications considered to the models for the division rates of initiated cells caused an inconsequential change in the fit of the model-predicted tumor incidence to the animal tumor data.

Figure D-41 Very similar model estimates of probability of fatal tumor in rats for three models in Figure D-39

Note: The differences are visually indistinguishable. Models were derived from the implementation of Conolly et al. (2003) with the hockey-stick curves for αI(flux) and αN(flux) and variants derived from modifications (Mod 1 and Mod 2, Figure D-39) to αI(flux). Model probabilities are compared to Kaplan-Meier estimates. The three sets of model estimates are so similar that they cannot be distinguished on this graph.

Source: Crump et al. (2008).

The above modifications did not affect the basal rate of cell division in the model and likewise had no effect on the fit to the human background data (Crump et al., 2008).

Crump et al. (2008) noted that, although the threshold model for initiated cells in Conolly et al. (2003) was replaced with a model that had a small positive slope at the origin, the resulting curves, hockey-stick Mod 1 and hockey-stick Mod 2, could have been shifted slightly to the right along the flux axis in order to introduce a threshold for α_I_ without materially affecting the risk estimates resulting from these modified curves. Thus, “the assumption of a linear no-threshold response is not an essential feature of the modifications to the hockey-stick model; clearly threshold models exist that would produce essentially the same effect” (Crump et al., 2008).

###### Biological plausibility of alternate assumptions

Crump et al. (2008) provide many arguments to support the very small variations made to the α_I_ in Conolly et al. (2003) for their sensitivity analyses. These variations are found to be:

- consistent with the tumor-incidence data (Figure D-41);
- small compared with the variability and uncertainty in the cell replication rates characterized from the available empirical data (at the formaldehyde flux where α_I_ was varied);
- supported (qualitatively) by limited data, suggesting increased cell proliferation at doses below cytotoxic;
- perturbations to be expected on any dose response derived from laboratory animal data because of human population variability in cell replication (the Conolly et al. (2004) modeling assumes that the formaldehyde flux levels at which cell replication, normal and initiated, exceeds baseline rates remain essentially unchanged when extrapolated to the human.)

The analyses of the cell replication data show that the data are not consistently (over each site and time) indicative of a hockey-stick or J shape as the best representation of the data; in some cases, the data appear to be more representative of a monotonic increasing dose response without a threshold. This uncertainty is particularly prominent when examining the cell replication data at the 13-week exposure time and the pooled data from the PLM nasal site from Monticello et al. (1996) (Appendix D.2.2 “Characterization of uncertainty-variability in cell replication rates”). The earliest exposure time in this experiment was at 13 weeks; it is possible that early times are of more relevance to the carcinogenesis as well as for considering typical (frequent short duration) human exposures. Meng et al. (2010) measured cell replication in the anterior lateral meatus of the F344 rat using continuous labeling on rats exposed to all the concentration levels in the Monticello et al. (1996) experiment. Labeling index (i.e., LI, as opposed to ULLI in the Monticello experiment) was measured as the percentage of BrdU-labeled cells among the total number of cells counted at the nasal site. Their data are reproduced below in Figure D-42, where the asterisk denotes the observation of a statistically significant difference from the control group (Dunnett’s test, p < 0.01). EPA determined that a linear regression provided good fits to all of the data (R^2^ = 0.97) as well as to the subset of the data obtained by deleting the higher dose data at 10 and 15 ppm exposures (R^2^ = 0.84). Thus, these data appear to be consistent with a monotonically increasing trend in the dose-response for cell replication.

For initiated cells, there are no data on which to evaluate the modifications made in Figures D-39 and D-40 to the assumption in equation 5-4. However, some perspective can be gained by comparing them to the variability in the division rates obtained from the data on normal cells used to construct the formaldehyde model. As shown in Figure D-25 and discussed further in Subramaniam et al. (2008), these data show roughly an order of magnitude variation in the cell replication rate at a given flux. As part of a statistical evaluation of these data, a standard deviation of 0.32 was calculated for the log-transforms of individual measurements of division rates of normal cells (Crump et al., 2008). By comparison, the maximum change in the log-transform division rate of initiated cells resulting from hockey-stick Mod 2 was only 0.20, and the average change would be considerably smaller. Thus, although there are no data for initiated cells, it can be said that the modifications introduced in Crump et al. (2008) for initiated cells are extremely small in comparison to the dispersion in the data for normal cells.

Figure D-42 Cell proliferation data from Meng et al. (2010)

The y-axis shows the percentage of BrdU-labeled among the total number of cells counted in the ALM section of the rat nose.

Reproduced with permission from (Meng et al., 2010).

###### Effect of alternate assumptions for initiated cell kinetics on human risk estimates

Figure D-43 contains graphs of the additional human risks estimated [in (Crump et al., 2008)] by applying these modified models or α_I_ and using all NTP controls, compared with those obtained by using the original (Conolly et al., 2004) model. Each of the four modified models presents a very different picture from that of (Conolly et al., 2004). At low exposures, these risks are three to four orders of magnitude larger than the largest estimates obtained by (Conolly et al., 2004).

Figure D-43 Graphs of the additional human risks estimated by applying these modified models for α_I_, using all NTP controls, compared to those obtained using the original (Conolly et al., 2004) model

Source: Crump et al. (2008).

These results have been criticized by (Conolly et al., 2009) as being unrealistically large and above the realm of any epidemiologic estimate for formaldehyde SCC. Thus, they argue that the parameter adjustments made in (Crump et al., 2008). are inappropriate. Crump et al. (2009) rebutted these points by arguing that the purpose of their work was not to provide a more reliable or plausible model but to carry out a sensitivity analysis. They argued that the changes made to the model (in their analyses) were reasonable because they did not violate any biological constraints or the available data. Further, they pointed out that “by appropriately mitigating the small modifications [they] made to the division rates of initiated cells, the model [would] provide any desired risk ranging from that estimated by the original model up to risks 1,000-fold larger than the conservative estimate in Conolly et al. (2004).”

Crump et al. (2008) also evaluated the assumption in equation D-21 of the CIIT modeling pertaining to initiated cell death rates (β_I_) by making small changes to β_I_. They report that they obtained similarly large values for estimates of additional human risk at low exposures. Obtaining reliable data on cell death rates in the nasal epithelium appears to be an unusually difficult proposition (Monticello and Morgan, 1997; Hester et al., 2003), and, even if data are obtained, they are likely to be extremely variable.

### D.2.3 Supporting Information for Lymphohematopoietic Cancer Estimates

This section presents the attempts to derive a unit risk estimate for myeloid leukemia based on the results of the NCI cohort study (Beane Freeman et al., 2009) and discusses the uncertainties associated with the available estimates.

Beane Freeman et al. (2009) used log-linear Poisson regression models stratified by calendar year, age, sex, and race and adjusted for pay category (salary/wage/unknown) to estimate RRs for various categorical exposure groups (see Table D-42). The NCI investigators used the low-exposure category as the reference category to “minimize the impact of any unmeasured confounding variables since nonexposed workers may differ from exposed workers with respect to socioeconomic characteristics” (Hauptmann et al., 2004b). A 2-year lag interval was used to determine exposures to account for a latency period for LHP cancers.

The log-linear trend tests conducted by Beane Freeman et al. (2009) used exposure as a continuous variable (except for peak exposure, for which categorical ranks were used) (general model form: RR = e^βX^, where β represents the regression coefficient and X is exposure). As shown by Callas et al. (1998), the Poisson regression model converges to the Cox proportional hazards model as the age strata are made infinitely small, and when age is well characterized and adjusted for, as it was in the (Beane Freeman et al., 2009) Poisson regression model, these two models yield essentially the same RR point estimates and CIs.

Dr. Beane Freeman provided EPA with the regression coefficient estimates from the log-linear trend test models for cumulative exposure for several LHP cancer subtype groupings. These estimates are presented in Table D-43. As with the NPC calculations, the nonexposed person-years were included in the primary unit risk estimate derivations and other quantitative approaches to be more inclusive of all the exposure-response data. Results for the exposed person-years only are presented for some of the unit risk estimates for comparison.

Table D-42 Relative risk estimates for mortality from multiple myeloma (ICD-8 code 203), leukemia (ICD-8 codes 204–207), myeloid leukemia (ICD-8 code 205), and other/unspecified leukemia (ICD-8 code 207) by level of formaldehyde exposure for different exposure metrics

Cancer type | Relative risk (number of deaths) | | | | p-Trend
Cancer type | Relative risk (number of deaths) | | | | All personyears^a^ | Exposed only^b^
Peak exposure (ppm)
| 0 | >0 to <2.0^c^ | 2.0 to <4.0 | ≥4.0
Multiple myeloma | 2.74 (11) | 1.0 (14) | 1.65 (13) | 2.04 (21) | >0.50 | 0.08
Leukemia | 0.59 (7) | 1.0 (41) | 0.98 (27) | 1.42 (48) | 0.02 | 0.12
Myeloid leukemia | 0.82 (4) | 1.0 (14) | 1.30 (11) | 1.78 (19) | 0.07 | 0.13
Other/unspecified leukemia | 0.61 (2) | 1.0 (13) | 0.86 (8) | 1.15 (13) | 0.50 | >0.50
Average Intensity (ppm)
| 0 | >0 to <0.5^c^ | 0.5 to <1.0 | ≥1.0
Multiple myeloma | 2.18 (11) | 1.0 (25) | 1.40 (11) | 1.49 (12) | >0.50 | >0.50
Leukemia | 0.54 (7) | 1.0 (67) | 1.13 (25) | 1.10 (24) | 0.50 | >0.50
Myeloid leukemia | 0.70 (4) | 1.0 (24) | 1.21 (9) | 1.61 (11) | 0.40 | 0.43
Other/unspecified leukemia | 0.58 (2) | 1.0 (21) | 0.98 (7) | 0.84 (6) | >0.50 | >0.50
Cumulative Exposure (ppm × years)
| 0 | >0 to <1.5^c^ | 1.5 to <5.5 | ≥5.5
Multiple myeloma | 1.79 (11) | 1.0 (28) | 0.46 (5) | 1.28 (15) | >0.50 | >0.50
Leukemia | 0.53 (7) | 1.0 (63) | 0.96 (24) | 1.11 (29) | 0.08 | 0.12
Myeloid leukemia | 0.61 (4) | 1.0 (26) | 0.82 (8) | 1.02 (10) | 0.44 | >0.50
Other/unspecified leukemia | 0.77 (2) | 1.0 (15) | 1.65 (10) | 1.44 (9) | 0.13 | 0.15

a Likelihood ratio test (1 degree of freedom) of zero slope for formaldehyde exposure (continuous variable, except for peak exposure metric) among all (nonexposed and exposed) person-years.

b Likelihood ratio test (1 degree of freedom) of zero slope for formaldehyde exposure (continuous variable, except for peak exposure metric) among exposed person-years only.

c Reference category for all categories with the same exposure metric.

Source: Beane Freeman et al. (2009).

Table D-43 Regression coefficients for leukemia, myeloid leukemia, and myeloid plus other/unspecified leukemias mortality from NCI trend test models of cumulative exposure^a^

Cancer type | Person-years | β (per ppm × years) | Standard error (per ppm × years)
Leukemia | All | 0.01246 | 0.006421
Leukemia | Exposed only | 0.01131 | 0.00661
Myeloid leukemia | All | 0.009908 | 0.01191
Myeloid leukemia | Exposed only | 0.008182 | 0.01249
Myeloid leukemia plus other/unspecified leukemia^b^ | All | 0.01408 | 0.007706
Myeloid leukemia plus other/unspecified leukemia^b^ | Exposed only | 0.01315 | 0.007914

a Models were stratified by calendar year, age, sex, and race and adjusted for pay category; exposures included a 2-year lag interval.

b p-trend values for the myeloid and other/unspecified leukemia categories combined are 0.10 for all person-years and 0.13 for exposed person-years only.

Source: Personal communication from Laura Beane Freeman to Jennifer Jinot (Jinot and Beane-Freeman, 2014)

#### Approaches Used for Quantitative Risk Assessment of Myeloid Leukemia

As discussed above, cumulative exposure, which incorporates both exposure intensity and duration, is the preferred exposure metric for the evaluation of long-term exposure to chemicals and effects on cancer, and it is the exposure metric of choice for the estimation of cancer risks in this assessment. EPA explored several approaches for deriving a unit risk estimate for myeloid leukemia based on cumulative exposure.

EPA considered a standard approach for deriving the unit risk estimate using the regression coefficient for myeloid leukemia and cumulative exposure; however, the p-value (0.44) for that regression coefficient was far from 0.05, indicating a poor model fit. The poor model fit could be due, at least in part, to inadequate statistical power, likely exacerbated by the underreporting of myeloid leukemia deaths suggested by the analyses by (Percy et al., 1981; Percy et al., 1990). Table D-43 shows that the regression coefficient for all person-years for myeloid leukemia is only slightly lower than that for all leukemia, which had a lower p-value of 0.08 and which should include all the myeloid leukemia deaths, both specified and unspecified. The “other/unspecified” leukemias comprise a sizable portion of all leukemia deaths (almost 30%) in the cohort and presumably include a good proportion of unclassified myeloid leukemias. The results of two NCI studies done at different times to evaluate the accuracy of death certificates by comparing the underlying cause of death on death certificates to original hospital diagnoses suggest that a third to a half of leukemias not otherwise specified on death certificates were diagnosed as myeloid leukemias in the hospital (Percy et al., 1981; Percy et al., 1990).^36^ Thus, two additional approaches for deriving a unit risk estimate for myeloid leukemia, which attempted to address the underreporting of myeloid leukemias, were considered.

One approach involved using the all leukemia grouping.^37^ Use of the all leukemia background rates in the life-table calculations (described in more detail below) might inflate the unit risk estimate by increasing the background risk relative to which the formaldehyde-related risks are calculated. However, the inclusion of any leukemia subtypes not related to formaldehyde exposure should theoretically dampen the exposure-response relationship (lowering the regression coefficient) relative to that for all the myeloid leukemias alone; thus, this should mitigate at least some of the effect of using the “all leukemia” background rates.

The approach considered by EPA to be the best currently available involved using a combined grouping of the myeloid leukemia and other/unspecified leukemias subcategories. The myeloid and other/unspecified leukemias grouping had a stronger association with cumulative exposure (p-trend = 0.10 for all person-years) in the Beane Freeman et al. (2009) study than did myeloid leukemia alone and it captures the unclassified myeloid leukemias with the least inclusion of nonmyeloid leukemias. There is likely more uncertainty associated with the background rates for the other/unspecified leukemias than for the specified myeloid and lymphocytic leukemia subtypes (discussed further below); however, the benefits of focusing on the myeloid plus other/unspecified leukemias rather than the broader “all leukemias” grouping in attempting to be more inclusive of all the myeloid leukemias were deemed to outweigh any additional uncertainty associated with the background rates.

Although the unit risk estimate based on the approach of using myeloid plus other/unspecified leukemias inevitably includes some nonmyeloid leukemias, it is considered by EPA to be the best of the currently available approaches for deriving a unit risk estimate for myeloid leukemia specifically.^38^ Results for all the approaches will be presented for comparison, and it will be apparent that the different approaches yield similar unit risk estimates. Because the purpose in presenting the results from the various approaches is to compare relative quantitative differences across the different approaches, not all the sensitivity analyses that would be presented in a final assessment were performed for each approach (e.g., performing comparison analyses based on exposed person-years only).

#### Prediction of Lifetime Extra Risk of Myeloid Leukemia Mortality and Incidence

Lifetime extra risk estimates for myeloid leukemia mortality were calculated from the regression results using the different approaches discussed above and the same general methodology described for the NPC mortality estimates. U.S. age-specific 2006 all-cause mortality rates (NCHS, 2009) were used in the life-table programs. For the cause-specific background mortality rates, NCHS age-specific 2006–2010 mortality rates for all race and sex groups combined were used for all leukemia (http://seer.cancer.gov/csr/1975_2010/results_merged/sect_13_leukemia.pdf) and (NCHS, 2006) age-specific mortality rates were used for myeloid leukemia (ICD-10 C92) and for other/unspecified leukemias (C94-C95) (NCHS, 2006). In addition, a 2-year lag period was used, as selected by (Beane Freeman et al., 2009).

The resulting point estimates and one-sided 95% UCLs for the extra risk of myeloid plus other/unspecified leukemias are shown in Table D-44. The model predicts extra risk estimates that are fairly linear for exposures below about 0.01–0.1 ppm (0.012-0.123 mg/m^3^) but not for exposures above 0.1 ppm (0.123 mg/m^3^).

Table D-44 Extra risk estimates for myeloid plus other/unspecified leukemia mortality from various levels of continuous lifetime exposure to formaldehyde

Exposure concentration (ppm^a^) | Extra risk | 95% UCL on extra risk
0.0001 | 1.32 × 10^−6^ | 2.51 × 10^−6^
0.001 | 1.32 × 10^−5^ | 2.51 × 10^−5^
0.01 | 1.34 × 10^−4^ | 2.58 × 10^−4^
0.1 | 1.59 × 10^−3^ | 3.38 × 10^−3^
1 | 8.40 × 10^−2^ | 6.26 × 10^−1^
10 | 9.81 × 10^−1^ | 9.90 × 10^−1^

a Values used in the derivation of the unit risk estimate are presented in ppm throughout this section. To convert from ppm to mg/m^3^, 1ppm = 1.23 mg/m^3^.

Although the background mortality rates of leukemia are higher (lifetime risk of 0.0062 according to the life-table analysis) than those of NPC, the 1% extra risk level typically used as the basis for the POD for epidemiological data still corresponds to an RR estimate (2.5) that would be above the highest categorical result reported, even after adjusting the RR estimates upward relative to the 0-exposure group (because our primary analyses include the nonexposed workers). A 0.5% extra risk level yields an RR estimate of 1.8, which better corresponds to the RRs in the range of the data. Thus, the LEC value corresponding to 0.5% extra risk (LEC_005_) was selected for the POD for all leukemia and for myeloid leukemia and myeloid plus other/unspecified leukemias, which have lower background rates than all leukemia (lifetime risks of 0.0031 and 0.0046, respectively).

There are insufficient data to establish the MOA(s) for formaldehyde-induced myeloid leukemia; thus, linear low-dose extrapolation was performed, in accordance with EPA’s Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005). The EC_005_, LEC_005_, and IUR estimates for myeloid plus other/unspecified leukemia mortality are presented in Table D-45.

Table D-45 EC_005_, LEC_005_, and inhalation unit risk estimates for myeloid plus other/unspecified leukemia mortality from formaldehyde exposure based on log-linear trend analyses of cumulative exposure data from the Beane Freeman et al. (2009) study

Person-years | EC_005_ (ppm) | LEC_005_ (ppm) | Unit risk^a^ (per ppm) | Unit risk (per mg/m^3^)
All | 0.253 | 0.133 | 3.8 × 10^−2^ | 3.1 × 10^−2^
Exposed only | 0.269 | 0.135 | 3.7 × 10^−2^ | 3.0 × 10^−2^

a Unit risk = 0.005/LEC_005_.

All leukemia and myeloid leukemia have substantial survival rates^39^; thus, it is preferable to derive incidence estimates. Unit risk estimates for leukemia incidences were calculated as described above for the NPC incidence estimates. Age-specific background incidence rates for 2006–2010 for leukemia and its major subtypes (myeloid and lymphocytic leukemia) from Surveillance, Epidemiology, and End Results (SEER) 18, a registry covering about 28% of the U.S. population, were obtained from the SEER website (http://seer.cancer.gov/csr/1975_2010/results_merged/sect_13_leukemia.pdf). Age-specific background incidence rates for other/unspecified leukemias were estimated by subtracting the myeloid and lymphocytic leukemia rates from the rates for all leukemia; these estimated rates would also include monocytic leukemia, but the contribution of monocytic leukemia is negligible.

The incidence-based calculation relies on the assumptions that incidence and mortality for these leukemia subtype groupings have the same exposure-response relationship for formaldehyde exposure and that the incidence data are for first occurrences of the cancers or that relapses provide a negligible contribution. The first assumption is more uncertain for all leukemia, myeloid leukemia, and myeloid plus other/unspecified leukemias than it was for NPC because these are groupings of subtypes with quite different survival rates (e.g., see footnote ^40^). The incidence-based calculation also takes advantage of the fact that incidence rates for these cancer types are negligible compared with the all-cause mortality rates and thus no special adjustment to the population at risk to account for live individuals who have been diagnosed with these cancers is necessary.

The EC_005_, LEC_005_, and IUR estimates for myeloid plus other/unspecified leukemia incidence are presented in Table D-46. The incidence unit risk estimate is about 10% higher than the mortality estimate. This difference is lower than the ~24% increase that would have been seen for specified myeloid leukemias alone (i.e., ICD-8 205). This is because the difference between age-specific mortality and incidence rates for the other/unspecified leukemias is not very large, and for some age groups the mortality rates are actually larger than the incidence rates. This irregularity is to be expected for “other/unspecified” classifications because greater attention is given to diagnosing incident leukemia cases than to accounting for causes of death, so one would anticipate less underreporting of myeloid leukemias as incident cases than as causes of death on death certificates.

Table D-46 EC_005_, LEC_005_, and inhalation unit risk estimates for myeloid plus other/unspecified leukemia incidence from formaldehyde exposure based on Beane Freeman et al. (2009) log-linear trend analyses for cumulative exposure

Person-years | EC_005_ (ppm) | LEC_005_ (ppm) | Unit risk^a^ (per ppm) | Unit risk (per mg/m^3^)
All | 0.224 | 0.118 | 4.2 × 10^−2^ | 3.4 × 10^−2^
Exposed only | 0.239 | 0.120 | 4.2 × 10^−2^ | 3.4 × 10^−2^

a Unit risk = 0.005/LEC_005_.

The EC_005_ and LEC_005_ estimates for mortality and incidence and incidence unit risk estimates for all leukemia and for myeloid leukemia using the alternate approaches discussed above are presented in Table D-47. The same underlying life-table methodology was used for each of these approaches—only the regression coefficients and background cancer rates differed. As discussed above, and consistent with the results just presented, EPA interprets the best available approach (shaded in Tables D-46 to D-48) to be the life-table analysis using the regression coefficient and background rates for myeloid plus other/unspecified leukemias because this grouping captures the unclassified myeloid leukemias with the least inclusion of nonmyeloid leukemias.

Table D-47 EC_005_ and LEC_005_ estimates for mortality and incidence and incidence unit risk estimates for all leukemia and for myeloid leukemia using alternate approaches (all person-years)

Approach (by cancer type used as basis for regression coefficient and cause-specific background rates) | EC_005_; (ppm) LEC_005_ (ppm) | | Unit risk estimate; (per ppm)^a^ | Unit risk estimate; (per mg/m^3^)
Approach (by cancer type used as basis for regression coefficient and cause-specific background rates) | Incidence | Mortality | (Incidence) | (Incidence)
Myeloid leukemia | 0.378; 0.127 | 0.468; 0.157 | 3.9 × 10^−2^ | 3.2 × 10^−2^
All leukemia | 0.156; 0.0846 | 0.229; 0.124 | 5.9 × 10^−2^ | 4.8 × 10^−2^
Myeloid + Other/Unspecified ^b^ | 0.224; 0.118 | 0.253; 0.133 | 4.2 × 10^−2^ | 3.4 × 10^−2^

Note: Shaded estimate is considered by EPA to be the best available estimate.

a Unit risk estimate = 0.005/(LEC_005_ for incidence).

b Incidence background rates also include monocytic leukemia, but that contribution is negligible.

#### Summary of the Best Available Unit Risk Estimate for Myeloid Leukemia

The best available unit risk estimate for myeloid leukemia is the estimate of 4.2 × 10^–2^ per ppm (3.4 × 10^−2^ per mg/m^3^) derived using incidence rates (and regression coefficient) for myeloid plus other/unspecified leukemias, for all (exposed and nonexposed) person-years.^40^ The results from the exposed person-years only are essentially indistinguishable (see Table D-46). The unit risk estimates from the other approaches considered are fairly close, with the unit risk estimate based on the myeloid leukemia category being virtually identical to the estimate based on myeloid plus other/unspecified leukemias and the estimate based on all leukemia being somewhat greater (see Table D-47).

Table D-48 summarizes some of the key information comparing the different approaches considered for the derivation of the unit risk estimate for myeloid leukemia.

Table D-48 Exposure-response modeling (all person-years) and (incidence) unit risk estimate derivation results for different leukemia groupings

Cancer grouping | Number of deaths in NCI cohort | Regression coefficient (per ppm × year) | SE (per ppm × year) | p-Value | Unit risk estimate (per ppm) | Unit risk estimate (per mg/m^3^)
Myeloid leukemia | 48 | 0.009908 | 0.01191 | 0.44 | 3.9 × 10^−2^ | 3.2 × 10^−2^
All leukemia | 123 | 0.01246 | 0.006421 | 0.08 | 5.9 × 10^−2^ | 4.8 × 10^−2^
Myeloid + Other/Unspecified leukemias | 84 ^a^ | 0.01408 | 0.007706 | 0.10 | 4.2 × 10^−2^ | 3.4 × 10^−2^

Note: Shaded estimate is considered by EPA to be the best currently available, although notably uncertain.

a This is the sum of the leukemias classified as myeloid and those classified as “other/unspecified.” At least 70–80% of this number is expected to be myeloid leukemias, assuming that a third to a half of leukemias not otherwise specified on death certificates are myeloid leukemias, as discussed above.

In summary, as discussed above, EPA explored several approaches for deriving a unit risk estimate for myeloid leukemia based on cumulative exposure. The first approach involved using the grouping of leukemias classified as myeloid leukemia on the death certificate. The regression coefficient for this grouping had a p-value (0.44) indicative of a poor model fit. It was reasoned that the poor model fit could be due, at least in part, to the underreporting of myeloid leukemia deaths discussed above. It can be seen in Table D-48 that the regression coefficient for myeloid leukemia is only slightly lower than that for all leukemia, which had a lower p-value of 0.08 and should include all the myeloid leukemia deaths, both specified and unspecified. Thus, a second approach involved using the all leukemia grouping, which includes other subtypes likely not associated with formaldehyde exposure. The approach considered by EPA to be the best available involved using the combined grouping of the myeloid leukemia and other/unspecified leukemias subcategories. The myeloid and other/unspecified leukemias grouping had a stronger association with cumulative exposure (p = 0.10) in the Beane Freeman et al. (2009) study than did myeloid leukemia alone and it captures the unclassified myeloid leukemias with the least inclusion of nonmyeloid leukemias. The benefits of focusing on the myeloid plus other/unspecified leukemias rather than the broader “all leukemia” grouping in attempting to be more inclusive of all the myeloid leukemias were deemed to outweigh any additional uncertainty associated with the background rates for the other/unspecified leukemias (discussed further below). It is reassuring that the unit risk estimates from the three different approaches are quite similar, with the estimate based on myeloid plus other/unspecified leukemias being essentially identical to the estimate based on the myeloid leukemia category and both those estimates being about two-thirds of the estimate for all leukemia.

#### Uncertainties in the Best Available Unit risk Estimate for Myeloid Leukemia

Important uncertainties associated with the best available estimate for myeloid leukemia are discussed below and summarized in Section 5.2.2 of the Toxicological Review.

- Despite the quality of the literature base for the formaldehyde assessment and the confidence in the qualitative hazard information for myeloid leukemia, the only study suitable for dose-response quantification for myeloid leukemia may be viewed as insufficient for developing a quantitative estimate of risk with an acceptable level of confidence.
  ○ The Beane Freeman study (2009) failed to observe an association between cumulative formaldehyde exposure and myeloid leukemia (p = 0.44), despite a reasonable number of cases (n = 48) and adequate follow-up. The peak exposure metric was marginally associated (p = 0.07). This result raises questions about the relative importance of the intensity of exposure and duration in the association of myeloid leukemia mortality. On the other hand, myeloid leukemia mortality increased with TSFE, cumulative exposure, and exposure duration in two other occupational cohorts (garment workers and embalmers).
  ○ The available animal studies do not provide evidence supporting an association between formaldehyde inhalation and myeloid leukemia. Thus, there are no animal data that can be used to support the POD estimate that can be derived from the only suitable human study.
- Analyses from NCI comparing causes of death recorded on death certificates with original diagnoses in hospital records suggest a misclassification of myeloid leukemia cases (N = 48), with a significant proportion reported as “other/unspecified” (N = 36).
  ○ In the (Percy et al., 1981; Percy et al., 1990) studies, only about 10% of leukemia deaths were classified as “other or unspecified” based on hospital diagnoses [versus 29% from death certificates in the Beane Freeman et al. (2009) study], and 51% (Percy et al., 1981) and 53% (Percy et al., 1990) of leukemia deaths were myeloid leukemias based on hospital diagnoses [versus 39% from death certificates in the Beane Freeman et al. (2009) study], suggesting that about a third or more of the “other or unspecified” leukemia deaths in the Beane Freeman et al. (2009) study were probably myeloid leukemias. Percy et al. (1990) reported in their study that “Of the nearly 600 deaths from leukemia NOS (other or unspecified) nearly 50% were originally diagnosed as myeloid… Obviously myeloid leukemia is grossly underreported on death certificates.”
  ○ Because it is likely that a proportion of myeloid leukemia cases were reported as “other/unspecified,” a more complete estimate of the association of cumulative formaldehyde exposure with myeloid leukemia might be obtained using the regression results for a combination of myeloid leukemia and other/unspecified leukemia.
  ○ Although a unit risk estimate that combines myeloid leukemia and other/unspecified leukemia overtly includes cancer subtypes not necessarily causally related with the chemical exposure, it is sometimes the case that, due to data limitations, unit risk estimates are based on less directly causal groupings (e.g., all leukemias, or all lung cancers). The inclusion of unassociated cancer subtypes in the derivation of the regression coefficient should theoretically attenuate the association.
  ○ A comparison of the unit risk estimates for all leukemia, myeloid leukemia plus other unspecified leukemia, and myeloid leukemia (ICD-8/9: 205) indicates that all of the estimates are within a factor of 1.5. Unit risk estimates were 3.9 × 10^−2^, 4.2 × 10^−2^, and 5.9 × 10^−2^ for all leukemia, myeloid leukemia plus other unspecified leukemia, and myeloid leukemia (ICD-8/9: 205), respectively.
- The approach for combining myeloid leukemia and other/unspecified leukemia to estimate risk, while arguably consistent with the identified misclassification of myeloid leukemia on death certificates (Percy et al., 1981; Percy et al., 1990), is uncommon but retains significant quantitative uncertainties, including some inconsistencies in statistical results.
  ○ The combination of myeloid leukemia and other/unspecified leukemia in the regression model yields a p-value of 0.1. While the number of cases is increased by n = 36, cancers in this category, with the exception of the myeloid leukemia cases, were not identified to be causally related with formaldehyde exposure during the hazard evaluation. The inclusion of cancers not causally related with formaldehyde exposure would be expected to attenuate the association, but in contrast to this expectation, there was a stronger association for the regression model of other/unspecified leukemia alone (p = 0.13) compared to the model of myeloid leukemia alone (p = 0.44). There is not a clear explanation for why the association would be stronger for the more heterogeneous leukemia category.
  ○ There is likely more uncertainty associated with the background cancer rates in the U.S. population for the other/unspecified leukemias than for the specified myeloid and lymphocytic leukemia subtypes. The survival rates of the other/unspecified cancers had to be estimated by subtracting myeloid and lymphocytic leukemia rates from the rates for all leukemia.
- Given the completely unknown MOA for myeloid leukemia, it is possible, and perhaps likely, that there are dose and duration effects for the development of myeloid leukemia following formaldehyde inhalation that are not fully understood.
  ○ Acknowledging the complexity of the different dose metrics available in the observational studies, as well as the lack of an association between cumulative exposure and myeloid leukemia in the Beane Freeman study (2009), it is possible that the specific, individual exposure metrics in this study failed to fully capture the patterns of exposure with which the development of myeloid leukemia is causally related. Importantly, this concern is independent of the identified hazard for myeloid leukemia, as myeloid leukemia mortality was increased in association with the peak exposure metric in this study (industrial workers) and others, as well as with duration-dependent metrics including TSFE, cumulative exposure, and exposure duration in two other occupational cohorts (garment workers and embalmers).
  ○ As information supporting a nonlinear extrapolation from the identified POD is not available for myeloid leukemia, the current approach uses a default linear extrapolation. It is possible that additional study on the development of this cancer after formaldehyde exposure could provide support for the linear extrapolation or, alternatively, support a nonlinear approach.

### D.2.4 Estimates Using DNA Adduct Data in Animals and Background Incidence

Lu et al. (2010a) developed a highly sensitive MS method using [^13^CD_2_]-formaldehyde that reportedly distinguishes whether formaldehyde-induced hydroxymethyl-DNA monoadducts, in particular, the N^2^-hydroxymethyl-dG (N^2^-hmdG) adduct, originate from endogenous or exogenous sources of formaldehyde in rats and monkeys. In experiments using this technique, (Yu et al., 2015b; Moeller et al., 2011; Lu et al., 2010a; Lu et al., 2011) quantified these mono adducts formed from both sources in various tissues of rats and monkeys: nasal cavity, bone marrow, mononuclear white blood cells, spleen, thymus, tracheal bronchial lymph nodes, mediastinal lymph nodes, trachea, lung, kidney, liver, and brain. (Swenberg et al., 2011), (Starr and Swenberg, 2013) and (Starr and Swenberg, 2016) used these adduct measurements and data on the background incidences of nasopharyngeal cancer, Hodgkin lymphoma, and leukemia in the U.S. population to develop cancer risk estimates by attributing the background incidences to endogenous formaldehyde, using the measured endogenous N2-hmdG adducts formed by formaldehyde in specific tissues as a biomarker of exposure. Their method, described by the authors as a “bottom-up approach” for risk estimation used the following steps:

1. DNA mono-adducts were used in the risk model as a marker of exposure (i.e., repairable) as opposed to a marker of effect (i.e., heritable mutations). While both adducts were reportedly formed by endogenous formaldehyde, only N2-hmdG adducts were detectable from exogenous formaldehyde.
2. Adducts formed endogenously were distinguished from those formed due to exogenous sources using ^13^CD_2_-formaldehyde coupled with MS methods.
3. Endogenously and exogenously formed mono-adducts were measured in various tissues: nasal cavity, bone marrow, spleen, thymus, and mononuclear white blood cells (rats); nasal cavity, bone marrow (monkeys).
4. Adducts were measured in rats after one 6-hour exposure to 0.7, 2.0, 5.8, 9.1, and 15.2 ppm formaldehyde and five 6-hour exposures to 10 ppm, and in monkeys (cynomolgus macaques) after two 6-hour exposures to 2 and 6 ppm. There were no measurements carried out in unexposed animals. Time-course data were used to derive the half-life (t_1/2_) for repair of the N2-hmdG adduct in rats.
5. No exogenous adducts were detected in any of the distant tissues (bone marrow, spleen, thymus, white blood cells); therefore, for these tissues the adduct levels were estimated by considering the limit of detection (LOD) of the method as an upper-bound estimate. This LOD was converted to the equivalent level of N2-hmdG adducts per 10^7^ dG.
6. The risk model assumes a linear relation between cancer incidence and N2-hmdG adduct levels (used as an intracellular marker of exposure) over the concentration range of endogenous adducts. The same linear model is then assumed for exogenous adducts in order to carry out an upward extrapolation to low exposures (that are not high enough to cause cytotoxicity). Unit risks for nasopharyngeal cancer (NPC), Hodgkin lymphoma (HL) and leukemia were calculated as follows:
  a. Determine lower confidence limits on the endogenous N2-hmdG adduct levels measured in Step 3.
  b. Assume the endogenous adduct level measured in rats to be the same in humans.
  c. Convert exogenous N2-hmdG adduct levels from 6-hour exposure values to adduct levels to be expected under steady-state continuous exposure using the estimated t1/2.
  d. Assume adduct levels are a linear function of exposure (adduct) concentration, passing through the origin. Calculate the adduct per ppm ratio. Then, from (c) above, calculate the continuous adduct level corresponding to 1 ppm.
  e. Convert the continuous adduct level corresponding to 1 ppm exposure from rat to human by assuming that adduct levels scale in proportion to formaldehyde flux to the nasal tissue in each species. For the monkey, assume that humans receive the same levels of formaldehyde flux.
  f. Consider endogenous and exogenous N2-hmdG adducts formed by formaldehyde to be biochemically indistinguishable (both were similarly related to low-dose formaldehyde carcinogenicity).
  g. Use the U.S. population background lifetime incidence probabilities of NPC (7.25 × 10^−4^), HL (2.3 × 10^−3^), and leukemia (1.3 × 10^−2^). (Swenberg et al., 2011) consider values provided in EPA’s 2010 draft Toxicological Review (for NPC) and the SEER Cancer Statistics Review (for HL and leukemia). Attribute these lifetime risks to the endogenous formaldehyde levels indicated by the adduct levels in step a (i.e., to the lower confidence limit on endogenous formaldehyde N2-hmdG adducts in the nose, bone marrow, or mononuclear white blood cells). Thus, calculate unit risk estimates for these specific cancers, expressed in units of risk per N2-hmdG adduct per 10^7^ dG.
  h. Using the unit risk estimates determined in Step g, calculate upper confidence limit on cancer risks for the continuous steady-state exogenous adduct level calculated in Step e, which corresponds to 1 ppm inhaled formaldehyde exposure concentration.

The authors state that their risk estimates are conservative upper bounds on added lifetime risk at low environmental exposures, and cite the following reasons as support:

– The background risks of specific cancers are fully attributed to the internal dose represented by the endogenous N2-hmdG adducts measured in the corresponding tissue.
– Only N2-hmdG adducts are included (the unit risk would be lower if other higher endogenous adducts are included).
– A linear risk model is assumed.
– Exogenous adduct levels are assumed to be a linear function of exposure concentration, passing through the origin. The slope of this line is based on the mean adduct concentration at 10 ppm exposure which is an overestimate at low exposures because the actual relationship of adduct levels versus ppm is highly nonlinear (upwardly concave). This leads to a more conservative estimate for the cancer risk from step h of #7 above.
– The 95% lower confidence bound on mean adduct level is used, which can be assumed to correspond to the upper confidence bound on estimated risk.
– Monkeys appear to have lower exogenous N2-hmdG adduct levels than rats; therefore, risk estimates based on scaling rat adduct levels to humans in proportion to formaldehyde flux to nasal tissue would likely err on the side of being an over-estimate for humans.

EPA (Crump et al., 2014) evaluated the assumption in (Swenberg et al., 2011) and (Starr and Swenberg, 2013) that their use of a linear risk model necessarily yields an upper bound on the low-dose risk. Since the approach in the updated (Starr and Swenberg, 2016) is the same as in (Starr and Swenberg, 2013), the evaluation in (Crump et al., 2014) elaborated further below equally holds.

By virtue of the additivity assumption (see bullet 6f above), the effective dose to the DNA is represented by the total N2-hmdG adduct (endogenous plus exogenous) level. That is, the bottom-up approach allows the traditional dose-response curve (extra risk versus externally derived dose) to be rescaled so that the dose measure associated with zero external dose is now considered a positive dose equal to the levels found in tissues not exposed to an external source, and the line of zero extra risk is at a positive risk designated as the background risk. This is shown schematically in Figure D-44. The dashed line, showing the linearly extrapolated risk to exogenous exposures, is the central estimate of the linear slope based on the background risk P_0_ of developing a specific cancer (attributed to an endogenous level of C_0_). The solid curve represents a plausible true dose-response for a case in which the curve shapes upward in the (unobservable) endogenous range. It is reasonable to assume that the shape of the true dose-response curve is differentiable at the endogenous adduct level and is concave upward at dose levels used in rodent bioassays (i.e., following typically used dose-response functions used in modeling the probability of tumor incidence, the slopes get steeper as dose increases and the second derivative is positive). Then it is clear from Figure D-44 that the bottom-up approach can never overestimate the relevant low-dose slope; any straight line between two points on the concave upward curve will underestimate the slope of the curve at the higher of the two doses. A similar argument can be made for a unit risk derived using a lower bound on C_0_ to calculate an upper bound on P_0_/C_0._

It is possible, nonetheless, that the extent of underestimation discussed above (that is, from a “bottom up” linear fit to a dose-response curve) can be offset by the conservatism in attributing all cancers of the specified type to the endogenous dose. However, this is difficult to assess. If one focuses only on the specified type of tumor, the assumption on its own appears to be conservative. It is not, however, easy to ascertain whether that degree of conservatism would be greater than the under-estimation. In addition, the selection of the type of cancer is informed by, and thus dependent on, higher dose data. To the extent the higher dose data did not detect other types of cancer, the attribution of all observed cases of the selected tumor may not capture all the relevant cases.

Furthermore, the slope of increased risk with increasing adduct levels need not be linear over the range of the endogenous adducts, especially near C_0_ or the lower bound on C_0_. Endogenous defensive mechanisms can become less effective in dealing with endogenous adduct levels as adduct levels increase over the endogenous range in which case the slope may be concave upward. This seems a plausible scenario, as organisms would have evolved some level of defensive mechanisms to deal with endogenous levels of adducts, yet there is an energy cost associated with over-capacity; thus, these defensive capabilities are not fully effective over the entire endogenous range, and this is consistent with the observance of “background” rates of cancer. Under this plausible scenario, the actual slope of the adduct-based unit risk estimate at the lower confidence bound on the mean endogenous N2-hmdG adduct level may be substantially higher than that suggested by the linear relationship assumed in (Starr and Swenberg, 2016). Thus, the slope obtained in Starr and Swenberg (2016) does not necessarily provide an upper bound on risk.

(Starr and Swenberg, 2013) note that the bottom-up approach is based on applying the concept of additivity to background disease processes (Crump et al., 1976). However, this concept of additivity to background only assumes local linearity in the proximity of zero exogenous dose to be reasonable, while the bottom-up approach assumes linearity over a large dose range; in particular, the bottom-up approach assumes a linear dose-response below zero exogenous dose, which is not required in the concept of additivity to background. As a result, it is unclear if, overall, the bottom-up approach results in a conservative bound on risk, given that extrapolation upwards in a sublinear dose-response would underestimate risk and underestimate the slope of the dose-response curve at higher doses. This is further discussed and illustrated in (Crump et al., 2014). Furthermore, the bottom-up approach assumes direct interaction of inhaled formaldehyde with a particular target tissue; if other sites of interaction and mechanisms are involved, the measures of DNA adducts in a specific tissue could lead to underestimates of the cancer potency when utilizing the “bottom-up” approach.

An additional uncertainty arises from the observation that while endogenous N2-hmdG and N6-hmdA adducts were both measured in rat and monkey nasal tissues, inhalation of formaldehyde resulted in a concentration-related pattern for exogenous N2-hmdG adducts only, and no detectable exogenous N6-hmdA adducts. If these differences (in regards the observation of N6-hmdA versus N2-hmdG adducts) are attributable to differences in the effects of endogenous versus exogenous formaldehyde in inducing DNA adducts, it is not clear that one can assume (as in bullet 6f above) additivity of endogenous and exogenous formaldehyde.

Thus, for multiple reasons, it does not appear to be possible to characterize the results using this approach as providing a conservative upper bound on cancer risk. Notwithstanding this limitation, the bottom-up approach in (Swenberg et al., 2011) and (Starr and Swenberg, 2016) is particularly attractive when other phenomena such as significant cytotoxicity and subsequent impact on DNA repair prior to mutations are occurring at higher doses. Because the approach does not use the higher-dose data (other than to identify the type of tumors of concern for analysis), it provides a unique perspective on risk estimates derived from these data.

Figure D-44 Schematic of the bottom-up approach

Source: Adapted from (Crump et al., 2014).

21 For each dichotomous endpoint, BMDS dichotomous models were fitted to the data using the maximum likelihood method. Each model was tested for goodness-of-fit using a chi-square goodness-of-fit test (χ^2^ p-value < 0.10 indicates lack of fit). Other factors were also used to assess model fit, such as scaled residuals, visual fit, and adequacy of fit in the low-dose region and in the vicinity of the BMR. For each continuous endpoint, BMDS continuous models were fitted to the data using the maximum likelihood method. Model fit was assessed by a series of tests as follows. For each model, first the homogeneity of the variances was tested using a likelihood ratio test (BMDS Test 2). If Test 2 was not rejected (χ^2^ p-value ≥ 0.10), the model was fitted to the data assuming constant variance. If Test 2 was rejected (χ^2^ p-value < 0.10), the variance was modeled as a power function of the mean, and the variance model was tested for adequacy of fit using a likelihood ratio test (BMDS Test 3). For fitting models using either constant variance or modeled variance, models for the mean response were tested for adequacy of fit using a likelihood ratio test (BMDS Test 4, with χ^2^ p-value < 0.10 indicating inadequate fit). Other factors were also used to assess the model fit, such as scaled residuals, visual fit, and adequacy of fit in the low-dose region and in the vicinity of the BMR.

22 Exposure assessment methodology was consistent with NIOSH Method 3500 (NIOSH, 1994).

23 (Hanrahan et al., 1984) reported on the “prevalence” of symptoms that had occurred since moving into the home.

24 Setting the intercept to other value such as 0.01, 0.02, 0.03 made little difference (e.g., at 0.03, the R^2^ had the same value of 0.9991, and the model was y = 6.1949x^3^ + 3.7689x^2^ + 0.0309x + 0.03.

25 Using a 1% background prevalence to estimate the exposure-response function and the BMC, yields an estimate of 0.154 ppm = 0.190 mg/m^3^ formaldehyde, and a BMCL estimate of 0.0768 = 0.0945 mg/m^3^; using a 2% background prevalence to estimate the exposure-response function and the BMC, yields an estimate of 0.154 ppm = 0.189 mg/m^3^ formaldehyde, and a BMCL estimate of 0.0739 = 0.0909 mg/m^3^.

26 Concentration (mg/m^3^) = Concentration (ppm) * (Molecular mass/Molar volume) = 0.155 ppm * [(30.03 g/mol)/(24.45 L)] = 0.191 mg/m^3^ at 25°C = Concentration (ppm) * 1.23.

27 Value converted based on 1 ppm = 1.23 mg/m^3^, assuming 25°C and 760 mm Hg.

28 United States Environmental Protection Agency. (2023). BMDS-Online (Build d5f505c8; Model Library Version 2023.03.1) [Web App]. Accessed on or around November 08, 2023.

29 Cases were defined as those whose doctors had prescribed asthma drug treatment at the time of the study (including the preceding year) (Venn et al., 2003).

30 Exposure measurements, pulmonary function measurements, and symptoms of asthma attacks were measured over a 4-week period.

31 To calculate the standard error of the ln(OR): [(ln(1.10) - ln(1.01)]/3.92 = 0.02178. Therefore, the 95% one-sided upper bound of the ln(OR) is [ln(OR)+1.645(0.02178)]=0.08461 and the 95% one-sided upper bound of the OR is 1.09.

32 Multb and multc were equal to 1.072 and 2.583, respectively (J-shaped αN), and 1.070 and 2.515, respectively (hockey-stick shaped αN).

33 Subramaniam et al. (2007) who also used the same data verified that they were on naïve rats; however, Conolly et al. (2000) state that they used data on preexposed rats.

34 Three animals in the inhalation historical controls were diagnosed with nasal SCC. Of these, two of the tumors were determined to have originated in tissues other than the nasal cavity upon further review (Dr. Kevin Morgan and Ms. Betsy Gross Bermudez, personal communication). These two tumors, therefore, were not included on the advice of Dr. Morgan. See Subramaniam et al. (2007) for more details.

35 The largest change in the tumor probability resulting from this modification for any dose group and any age up through 900 days was found to be less than 0.002, a change so small that it would be impossible to detect, even in the largest bioassays ever conducted. The changes in tumor probability resulting from the other modifications described earlier were found to be even smaller. These comparisons were made in Crump et al. (2008) without reoptimizing the likelihood. The authors note that reoptimization of the model subsequent to the variations would have made the fit of modified models even better.

36 In the (Percy et al., 1981; Percy et al., 1990) studies, only about 10% of leukemia deaths were classified as “other or unspecified” based on hospital diagnoses [versus 29% from death certificates in the (Beane Freeman et al., 2009) study], and 51% (Percy et al., 1981) and 53% (Percy et al., 1990) of leukemia deaths were myeloid leukemias based on hospital diagnoses [versus 39% from death certificates in the (Beane Freeman et al., 2009) study], suggesting that about a third or more of the “other or unspecified” leukemia deaths in the Beane Freeman et al. (2009) study were probably myeloid leukemias. Percy et al. (1990) reported in their study that “Of the nearly 600 deaths from leukemia NOS [other or unspecified] nearly 50% were originally diagnosed as myeloid… Obviously myeloid leukemia is grossly underreported on death certificates.”

37 The all leukemia category includes all 123 leukemias observed in the cohort. Of these, 48 (39.0%) were myeloid, 37 (30.1%) were lymphoid, and 36 (29.3%) were other/unspecified; the remaining 2 (1.6%) were monocytic leukemias (ICD-8 code 206).

38 Although the inclusion of cancer subtypes not necessarily causally associated with the chemical exposure in the grouping of cancers represented in the regression coefficient and the corresponding background rates for the life-table analysis is overt here, it is not uncommon that, due to data limitations, unit risk estimates based on human data reflect cancer groupings broader than what might be strictly causally associated with the chemical exposure (e.g., all leukemias, or all lung cancers). As noted in the text, any inclusion of unassociated cancer subtypes in the derivation of the regression coefficient should theoretically attenuate the coefficient in a manner that would offset the use of the unassociated subtypes in the background rates in the life-table analysis.

39 Survival rates were 55.0% at 5 years for all leukemia [http://seer.cancer.gov/statfacts/html/leuks.html], 23.4% at 5 years for acute myeloid leukemia [http://seer.cancer.gov/statfacts/html/amyl.html], and 59.1% at 5 years for chronic myeloid leukemia [http://seer.cancer.gov/statfacts/html/cmyl.html] based on 2002–2009 SEER data.

40 Comparable to calculations done for NPC (see Section 5.2.1 of the Toxicological Review), a rough calculation was done to ensure that the unit risk estimate derived for myeloid leukemia incidence is not implausible in comparison to actual case numbers. For example, assuming an average constant lifetime formaldehyde exposure level of 20 ppb for the U.S. population, the inhalation unit risk estimate for myeloid (and other/unspecified) leukemia equates to a lifetime extra risk estimate of 8.4 × 10^–4^. Assuming an average lifetime of 75 years (this is not EPA’s default average lifetime of 70 years, but rather a value more representative of actual demographic data) and a U.S. population of 300,000,000, this lifetime extra risk estimate suggests a crude upper-bound estimate of 3,400 incident cases of myeloid leukemia attributable to formaldehyde exposure per year. This upper-bound estimate is well below the estimated 17,100 total incident myeloid leukemia (not including other/unspecified leukemias) cases per year calculated from the SEER myeloid leukemia incidence rate of 5.7/100,000 (age-adjusted incidence rate for AML and CML combined from 2008–2012 SEER-18 data; www.seer.cancer.gov).