# APPENDIX C HAZARD IDENTIFICATION SUPPLEMENT

## C.1 TOXICOKINETICS OF INHALED AND ENDOGENOUS FORMALDEHYDE

This chapter presents specific information on the toxicokinetics [absorption, distribution, metabolism, and excretion (ADME)] of inhaled and endogenously produced formaldehyde from human and experimental animal studies. A summary of this information is presented in Section 3.1 of the Toxicological Review. Although toxicokinetics is typically discussed in a sequential manner [i.e., with absorption defined as delivery to the blood; distribution describing delivery to the target tissue(s); metabolism outlining conversion to a more-or-less active chemical species, which often occurs in liver or target tissue elsewhere; and excretion documenting tissue clearance and removal processes], the primary site of action of inhaled formaldehyde is at the portal of entry (POE), specifically within the upper respiratory tract (URT). Therefore, this section will first discuss the uptake (also referred to as “absorption” in the formaldehyde literature) of inhaled formaldehyde into the URT tissue, and its transport, metabolism, and removal within the POE. Following this is a description of what is known regarding the absorption of formaldehyde from the POE into the blood and the potential for distribution of exogenous formaldehyde to systemic sites, along with a discussion of formaldehyde metabolism and excretion processes that may occur outside of the POE.

Formaldehyde is produced endogenously during normal cellular metabolism and as a byproduct of lipid peroxidation, or as a product in the catabolism of other chemicals introduced through dietary, environmental, or pharmaceutical sources. Therefore, discussions of inhaled formaldehyde require a consideration of the potential impact of endogenous formaldehyde on its toxicokinetics, as well as on its toxicity. The available evidence on the metabolism and kinetics of endogenous formaldehyde is discussed within each of the following subsections specifically as it pertains to the toxicokinetics of exogenous formaldehyde.

In the last subsections, the available toxicokinetic models of formaldehyde are presented.

### C.1.1 Toxicokinetics of Inhaled Formaldehyde at the Portal of Entry (POE)

Formaldehyde is a highly reactive, highly water soluble, respiratory irritant, towards which the human body has developed several detoxification and removal processes at the site(s) of first contact (e.g., nasal passages for inhalation). Thus, this discussion of the toxicokinetics of inhaled formaldehyde at the POE is organized according to the most likely sites of first contact between inhaled formaldehyde and biological materials, in the context of the known anatomy and potential elimination processes of the respiratory tract tissues. Several of the key considerations for evaluating the toxicokinetics of inhaled formaldehyde at the POE in the rat nose are represented schematically in Figure C-1. The respiratory tract is divided broadly as (1) upper respiratory tract (URT), which includes the nasal cavity, pharynx, and larynx and (2) the lower respiratory tract (LRT) comprising the trachea, bronchi, and lungs. Species differences in the structure of the airways, as well as the composition of the surface epithelium at various nasal locations, are important considerations to keep in mind when interpreting results in rodents and extrapolating observations to humans. Nasal passages, starting from anterior to posterior, are lined by four different types of epithelia: (1) squamous or keratinized, stratified (nasal vestibule); (2) transitional or nonciliated cuboidal/columnar; (3) respiratory or ciliated pseudostratified cuboidal/columnar (main chamber and nasopharynx); and (4) olfactory (dorsal and dorsoposterior nasal cavity) (Harkema et al., 2006). It is important to note that rodents and humans differ in the distribution of nasal epithelial surfaces. For example, the olfactory epithelium in rats and mice makes up approximately 50–52% and 45–47%, respectively, of the nasal cavity surface area, whereas in humans, it makes up only 3% (Sorokin, 1988; Gross et al., 1982).

Figure C-1 Schematic of the rat upper respiratory tract depicting the gradient of formaldehyde concentration formed following inhalation exposure, both from anterior to posterior locations, as well as across the tissue depth

Modeling based on observations in rodents predicts a similar pattern of distribution in humans. Drawn based in part on images by (NRC, 2011) and (Harkema et al., 2006). Note: other components (e.g., naris; transitional epithelium) have been omitted to increase clarity.

### C.1.2 Spatial Distribution of Tissue Uptake of Formaldehyde at the Portal of Entry

The distribution of inhaled formaldehyde within the URT and LRT can provide information useful to interpreting any potential toxicity. The nasal passages in humans are generally similar to other mammalian species. One key difference, however, is that humans and nonhuman primates have nasal passages adapted for both oral and nasal (oronasal) breathing, as opposed to obligate nasal breathing in rodents. A second key difference is the shape and complexity of the nasal turbinates, with relatively simple shapes in humans, and complex, folded patterns in rodents. In general, these differences provide better protection of the rodent LRT against inhaled toxicants than is provided to the human LRT (Harkema et al., 2006).

#### Indirect measurement studies

Much of what is known regarding the uptake of formaldehyde is based on indirect measurements of formaldehyde-induced changes and/or molecular interactions, or removal of formaldehyde from the air. This is because, in biological systems, formaldehyde exists as total or analyzable formaldehyde, which includes free and reversibly bound (acid-labile) forms (Heck et al., 1982). Conventional methods cannot directly measure low levels of free formaldehyde with certainty in tissues and body fluids. Additionally, carbonyl impurities such as acetone, formaldehyde and acetaldehyde are present even in quartz distilled water and may interfere in the measurements (Esterbauer et al., 1982). Uptake of formaldehyde (defined as retention within the respiratory tract tissue), based on estimates determined from the amount of formaldehyde removed from the air, indicate that a majority of formaldehyde is removed from inhaled air by the URT.

Indirect estimates of formaldehyde uptake, based on interactions with cellular materials, have been made in experimental animals, including monkeys (Monticello et al., 1989; Casanova et al., 1991), dogs (Egle, 1972), and rats (Kimbell et al., 2001b; Kerns et al., 1983; Heck et al., 1983; Chang et al., 1983) as shown in Table C-1.

Table C-1 Dosimetry and response of formaldehyde in experimental animals by indirect measurements

Reference and species | Exposure and analysis | Observations
Casanova et al. (1991); Monkeys, rhesus; male, n = 9; mean ± SD = 8.74 ± 0.84; 4.6 year old | 0.86, 2.46, 7.38 mg/m^3^ for 6-hr [^14^C]CH_2_O from [^14^C]PFA. Estimated the amount of DNA-protein crosslinks (DPX) formed in various tissues | DPX Levels | | Area of the respiratory tract
Casanova et al. (1991); Monkeys, rhesus; male, n = 9; mean ± SD = 8.74 ± 0.84; 4.6 year old | 0.86, 2.46, 7.38 mg/m^3^ for 6-hr [^14^C]CH_2_O from [^14^C]PFA. Estimated the amount of DNA-protein crosslinks (DPX) formed in various tissues | Highest | | Middle turbinate mucosa
Casanova et al. (1991); Monkeys, rhesus; male, n = 9; mean ± SD = 8.74 ± 0.84; 4.6 year old | 0.86, 2.46, 7.38 mg/m^3^ for 6-hr [^14^C]CH_2_O from [^14^C]PFA. Estimated the amount of DNA-protein crosslinks (DPX) formed in various tissues | Lower | | Anterior lateral wall/septum and nasopharynx
Casanova et al. (1991); Monkeys, rhesus; male, n = 9; mean ± SD = 8.74 ± 0.84; 4.6 year old | 0.86, 2.46, 7.38 mg/m^3^ for 6-hr [^14^C]CH_2_O from [^14^C]PFA. Estimated the amount of DNA-protein crosslinks (DPX) formed in various tissues | Very low | | Larynx/trachea/carina
Casanova et al. (1991); Monkeys, rhesus; male, n = 9; mean ± SD = 8.74 ± 0.84; 4.6 year old | 0.86, 2.46, 7.38 mg/m^3^ for 6-hr [^14^C]CH_2_O from [^14^C]PFA. Estimated the amount of DNA-protein crosslinks (DPX) formed in various tissues | None | | Maxillary sinuses and lungs
Monticello et al. (1989) Monkeys, rhesus; male, n = 9; 4-6 years; 6-7 kg | 7.4 mg/m^3^, 6 hrs/d; 5 d/wk; 1 or 6 wk CH_2_O from PFA. Animals injected with [^3^H]-Thd, sacrificed, histoauto-radiography of cell proliferation measured | Proliferation | | Area of the respiratory tract
Monticello et al. (1989) Monkeys, rhesus; male, n = 9; 4-6 years; 6-7 kg | 7.4 mg/m^3^, 6 hrs/d; 5 d/wk; 1 or 6 wk CH_2_O from PFA. Animals injected with [^3^H]-Thd, sacrificed, histoauto-radiography of cell proliferation measured | Significant | | Nasal passages
Monticello et al. (1989) Monkeys, rhesus; male, n = 9; 4-6 years; 6-7 kg | 7.4 mg/m^3^, 6 hrs/d; 5 d/wk; 1 or 6 wk CH_2_O from PFA. Animals injected with [^3^H]-Thd, sacrificed, histoauto-radiography of cell proliferation measured | Minimal | | Lower respiratory tract
Monticello et al. (1989) Monkeys, rhesus; male, n = 9; 4-6 years; 6-7 kg | 7.4 mg/m^3^, 6 hrs/d; 5 d/wk; 1 or 6 wk CH_2_O from PFA. Animals injected with [^3^H]-Thd, sacrificed, histoauto-radiography of cell proliferation measured | None | | Maxillary sinuses
Egle (1972) Dogs/Mongrel; Male and female; n = 4; 13–19 kg | 150 to 350 mg/m^3^ CH_2_O vapors from [underlined: formalin]; nose-only inhalation from a respirometer; animals preanesthetized; aldehydes analyzed by a colorimetric method | Uptake at all ventilation rates and concentrations
Egle (1972) Dogs/Mongrel; Male and female; n = 4; 13–19 kg | 150 to 350 mg/m^3^ CH_2_O vapors from [underlined: formalin]; nose-only inhalation from a respirometer; animals preanesthetized; aldehydes analyzed by a colorimetric method | Total respiratory tract (TRT) | | | | | ≈100%
Egle (1972) Dogs/Mongrel; Male and female; n = 4; 13–19 kg | 150 to 350 mg/m^3^ CH_2_O vapors from [underlined: formalin]; nose-only inhalation from a respirometer; animals preanesthetized; aldehydes analyzed by a colorimetric method | URT- inhalation | | | | | 100%
Egle (1972) Dogs/Mongrel; Male and female; n = 4; 13–19 kg | 150 to 350 mg/m^3^ CH_2_O vapors from [underlined: formalin]; nose-only inhalation from a respirometer; animals preanesthetized; aldehydes analyzed by a colorimetric method | URT- inhalation + exhalation | | | | | ≈100%
Heck et al. (1983); Rats, Fischer; Male, n = 3; 18--250 g | Radioactivity immediately after 6hr exposure to [^14^C]CH_2_O from [^14^C]PFA, each averaging 3 exposures and 4 rats at 6.2, 12.3, 18.5, or 29.5 mg/m^3^ | | Equivalents of [^14^C] in various tissues (μmol/g)^a^ or mg/m^3^
Heck et al. (1983); Rats, Fischer; Male, n = 3; 18--250 g | Radioactivity immediately after 6hr exposure to [^14^C]CH_2_O from [^14^C]PFA, each averaging 3 exposures and 4 rats at 6.2, 12.3, 18.5, or 29.5 mg/m^3^ | | 6.15 | | 12.3 | 18.5 | | 29.5
Heck et al. (1983); Rats, Fischer; Male, n = 3; 18--250 g | Radioactivity immediately after 6hr exposure to [^14^C]CH_2_O from [^14^C]PFA, each averaging 3 exposures and 4 rats at 6.2, 12.3, 18.5, or 29.5 mg/m^3^ | Nasal Mucosa | 0.59 ± 0.18 | | 1.15 ± 0.29 | 1.78 ± 0.4 | | 2.28 ± 0.61
Heck et al. (1983); Rats, Fischer; Male, n = 3; 18--250 g | Radioactivity immediately after 6hr exposure to [^14^C]CH_2_O from [^14^C]PFA, each averaging 3 exposures and 4 rats at 6.2, 12.3, 18.5, or 29.5 mg/m^3^ | Trachea | 0.26 ± 0.13 | | 0.39 ± 0.13 | 0.36 ± 0.09 | | 0.40 ± 0.13
Heck et al. (1983); Rats, Fischer; Male, n = 3; 18--250 g | Radioactivity immediately after 6hr exposure to [^14^C]CH_2_O from [^14^C]PFA, each averaging 3 exposures and 4 rats at 6.2, 12.3, 18.5, or 29.5 mg/m^3^ | Plasma | 0.05 ± 0.01 | | 0.08 ± 0.01 | 0.10 ± 0.04 | | 0.11 ± 0.05

CH_2_O, formaldehyde; PFA, paraformaldehyde; DPX, DNA-protein crosslinks.

a Values, representing mean ± SD, were extracted from graphical data using GrabIT software.

As shown in Table C-1, (Casanova et al., 1991) used DNA-protein crosslinks (DPX) levels as a measure of regional dosimetry of formaldehyde in monkeys exposed to formaldehyde by inhalation assuming that the rate of crosslink formation depends on the concentration of formaldehyde delivered at the portal of entry tissues. They subjected rhesus monkeys to a single 6-hr exposure of formaldehyde over a range (0.9–7.4 mg/m^3^) and concluded based on the observed pattern of DPX formation that formaldehyde uptake primarily occurs in nasal passages involving middle turbinates, to a smaller extent in the nasopharynx and trachea, but not in maxillary sinuses or lungs (Casanova et al., 1991). Monticello et al. (1989) predicted the uptake of formaldehyde based on other indirect measures such as cell proliferation in monkeys exposed to 7.4 mg/m^3^ formaldehyde, 6 hours/day, 5 days/wk for 1 or 6 weeks. They concluded that formaldehyde uptake primarily occurs in nasal passages and middle turbinates, to a smaller extent in the nasopharynx and trachea, with evidence of increased proliferation in proximal regions of the bronchi, but no indication of effects in the maxillary sinuses. In dogs exposed to formalin vapors, almost 100% of inhaled formaldehyde is retained in the URT, indicating that little, if any, inhaled formaldehyde would reach the LRT, and this is independent of respiration rate, tidal volume, and inhaled formaldehyde concentration (Egle, 1972).

Similarly, radiolabeling studies, exemplified by (Heck et al., 1983) in rats show that the majority of the labeled formaldehyde is retained within the nasal passages and, to a far lesser extent, within the other parts of the URT and proximal LRT, with no evidence of significant distribution into plasma. However, because formaldehyde is incorporated into the one-carbon (1C) pool (see discussion later in this section), possibly facilitating its distribution in a toxicologically-inactive form, neither the distribution of radiolabel nor the estimated retention are interpreted to provide a clear picture of the spatial distribution of inhaled formaldehyde within the respiratory tract tissues. Notably, long-term exposure of rats to formaldehyde for 30 months induced lesions in the nasal cavity and proximal trachea (Kerns et al., 1983). Kimbell et al. (2001b) predicted the uptake of formaldehyde in the nasal passages of F344 rats, rhesus monkeys and humans to be respectively, 90%, 67% and 76% using the computational fluid dynamics (CFD) modeling. Similar to these predictions for rats, (Morgan et al., 1986c) demonstrated that rat nasal passages scrubbed nearly all of the inhaled formaldehyde (on average ≈97%). In rats, the evidence suggests that higher concentrations of formaldehyde are taken up in the respiratory mucosa as compared to the olfactory mucosa (Swenberg et al., 1983a; Casanova-Schmitz et al., 1984b).

#### Extrapolation using fluid dynamic modeling

There are no studies available in the literature that directly addressed uptake of formaldehyde into the respiratory tract of humans. However, a few modeling studies based on findings in rodents report estimated uptake of inhaled formaldehyde in humans (Overton et al., 2001; Kimbell et al., 2001b; Kimbell and Subramaniam, 2001). Kimbell et al. (2001b), using a three-dimensional, CFD model of the nose, predicted human nasal uptake of approximately 76% of the inhaled formaldehyde at unidirectional steady-state nasal inspiratory flow corresponding to sleeping activity, decreasing to 58% under heavy exercise activity. Overton et al. (2001) modeled overall uptake in the entire respiratory tract and predicted that 95% of inhaled formaldehyde is retained in the respiratory tract in general in any activity state. description of modeling efforts in human, monkeys and rats is provided in Appendix C.1.12. Overall, dosimetric modeling studies in humans have shown close agreement with observations of exposed rodents: namely, that 90–95% of inhaled formaldehyde is retained in the URT (Subramaniam et al., 1998; Overton et al., 2001; Kimbell et al., 2001b).

#### Relationship of formaldehyde uptake to endogenous levels and prior exposure

Heck et al (1982) developed a gas chromatography-mass spectrometry (GC-MS) method to measure total or analyzable formaldehyde, which includes both free as well as reversibly bound formaldehyde [hydrated formaldehyde bound to glutathione (GSH) and tetrahydrofolate (THF)]. However, this method does not measure irreversibly bound formaldehyde. Based on this method, endogenous formaldehyde levels were 1.5–4.3 folds higher at the POE (i.e., nasal mucosa; ≈12.6 μg/g or 0.42 mM) than in other tissues (i.e., testes<liver<brain) (Heck et al., 1982). It remains to be determined how this may affect the local toxicokinetics of inhaled formaldehyde.

Heck et al. (1983) also examined the effect of prior exposure to formaldehyde on tissue levels of formaldehyde in rats. As shown in Table C-2, no statistically significant changes in total formaldehyde levels in the nasal mucosa were observed following 10-day exposure of F344 rats to 7.4 mg/m^3^ formaldehyde (Heck et al., 1982), suggesting that formaldehyde exposure does not distinguishably augment total levels of formaldehyde in POE tissues. However, rats and mice appear to differ in the uptake of formaldehyde following repeated inhalation exposure to formaldehyde. Prior, short-term exposure to high levels of formaldehyde in rats did not alter uptake of formaldehyde into the respiratory mucosa during a subsequent exposure. This was based on comparisons between a single exposure to 18.5 mg/m^3^ in naïve rats compared to repeated exposures in rats exposed to the same dose of formaldehyde for the previous 9 days (Heck et al., 1983). In a different study, (Chang et al., 1983) also observed similar uptake in preexposed as well as naïve rats; however, mice responded differently, with naïve mice exhibiting more radioactivity uptake than preexposed mice (see Table C-2). The authors concluded that since mice tend to lower their minute volume with repeated exposures to formaldehyde, they tend to have less absorption, hence less radioactivity compared to naïve mice. So comparing the results in rats, which do not alter their minute volume as mice do, it was suggested that repeated exposure does not affect the uptake of formaldehyde in nasal cavity of rats (Chang et al., 1983).

Table C-2 Comparison of formaldehyde uptake at the portal of entry with single or repeated inhalation exposure

Reference and design | Exposure and analysis | Observations
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.4 mg/m^3^ [^13^C] CH_2_O (from PFA) for 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | Nasal mucosa levels total^a^ CH_2_O (μg/g^b^)
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.4 mg/m^3^ [^13^C] CH_2_O (from PFA) for 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | Unexposed; 12.6 ± 2.7 | Exposed; 11.7 ± 3.6
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | [underlined: 2 groups]: (a) preexposure; (b) naïve; On Days 1-9: [underlined: group a)] received 18.5 mg/m^3^ CH_2_O (from PFA); whole body exposure, 6 hrs/d; [underlined: group b)]: no preexposure. On Day 10: groups a and b received [^14^C] CH_2_O (from PFA) for 6 hrs, nose-only exposure. Tissue homogenates counted with LSC for ^14^CO_2_ trapped in ethanolamine in 2-methoxy-ethanol counted for radioactivity. | Equivalents of ^14^C in respiratory mucosa (μg /g^c^)
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | naïve rats | 67.5 ± 9.2
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | preexposed | 64.4 ± 7.6
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | (No significant difference)
Chang et al. (1983); Rats, Fischer;; Male, N=3;; 180-200 g; Mice, B6C3F1; Male, N=3; 22-26 g | i) [underlined: preexposure]:; 7.4 or 18.4 mg/m^3^ unlabeled CH_2_O from PFA, 6 hrs/d, 4-d whole-body exposure; on 5th d ^14^CH_2_O from PFA, 6 hrs; ii) [underlined: naïve animals]:; ^14^CH_2_O, 6 hrs from PFA | [underlined: Radioactivity in nasal cavity:] preexposed rats = naïve rats; [underlined: Radioactivity in nasal cavity:] naïve mice > pretreated mice

CH_2_O, formaldehyde; PFA, paraformaldehyde; PFPH, pentafluorophenylhydrazine; GC/MS, gas chromatography/mass spectrometry; LSC, liquid scintillation counting; CO_2_, carbon dioxide.

a Total formaldehyde includes free plus reversibly bound formaldehyde.

b Data from (Heck et al., 1982) given in µmols/g is converted to µg/g by the equation: µmols × 30 = µg/g (30 is the molecular weight of formaldehyde).

c Data from (Heck et al., 1983) given in nmols/g is converted to converted to µg/g by the equation: (nmol/g /1,000) × 30 = µg/g) (30 is the molecular weight of formaldehyde).

#### Summary of spatial distribution of POE uptake

To summarize, a majority of inhaled formaldehyde is rapidly absorbed and retained in the URT based on CFD modeling studies in humans (Subramaniam et al., 1998; Overton et al., 2001; Kimbell et al., 2001b; Kimbell and Subramaniam, 2001), indirect or direct measurements in monkeys (Monticello et al., 1989; Casanova et al., 1988), and direct measurements in dogs (Egle, 1972) and rats (Kimbell et al., 2001b; Kerns et al., 1983; Heck et al., 1983; Chang et al., 1983), despite the anatomical and physiological differences between species, such as obligate nose breathing in rodents (rats and mice) and oronasal breathing in primates (monkeys and humans) (Schreider, 1986; Harkema et al., 2006). As demonstrated in monkeys and rats, and as modeled in humans, a concentration gradient of inhaled formaldehyde follows an anterior to posterior distribution, with high concentrations of formaldehyde distributed to squamous, transitional, and respiratory epithelia, and less uptake by olfactory epithelium, and very little or no formaldehyde reaching more distal sites such as the larynx or lung. Further, at inhaled concentrations as high as 7.4 mg/m^3^, exogenous exposure does not appreciably change the levels of formaldehyde over the endogenous levels in the nasal mucosa (Heck et al., 1982). Also, repeated exposures to formaldehyde do not alter the tissue formaldehyde levels in rats, but naïve mice do show higher tissue uptake than preexposed mice, which is attributed to species differences in minute volume and response to irritant gases (Chang et al., 1983).

### C.1.3 Tissue Penetration of Formaldehyde Within the Upper Respiratory Tract

Within the URT, penetration of formaldehyde follows initial interaction with the mucociliary apparatus followed by diffusion into the epithelial cell layer where it can be metabolized. Important details to consider in evaluating formaldehyde nasal dosimetry and toxicity are the differences in the types of epitheliums lining the nasal surfaces. As described earlier, there are striking differences in the amount of olfactory epithelium and respiratory epithelium present between the noses of rats, which have a highly complex sense of smell, compared to humans, who use the nose primarily used for breathing. In all species, air (and formaldehyde) must first pass over squamous, transitional, and respiratory epithelium before coming in contact with olfactory epithelium. This section will focus on the interaction and fate of inhaled formaldehyde in the URT.

#### Formaldehyde interaction with the mucociliary layer

The mucociliary apparatus of the URT is the first line of defense against airborne agents in that it may entrap, neutralize, and remove particulates and airborne chemicals from inspired air (Morgan et al., 1983). The mucociliary apparatus is comprised of three layers: a thick mucus layer (epiphase) at the top, a watery fluid layer (hypophase) in the middle, and a ciliated epithelial layer at the bottom (Schlosser, 1999). Inhaled formaldehyde must pass through the mucus layer covering the URT before it can react with the cellular components in this region.

The respiratory mucus is composed of 97% water, 2–3% glycoproteins, 0.3–0.5% fats, and about 0.1–0.5% soluble proteins (Bogdanffy et al., 1987). Formaldehyde gas (unhydrated) is highly soluble in water, in which it hydrolyzes to a reversible hydrated form called methanediol or methylene glycol with a half-life of 70 milliseconds and with an equilibrium constant [CH_2_O]/[CH_2_(OH)_2_] of 4.5 × 10^−4^ at 22°C (Sutton and Downes, 1972). In aqueous solution, most of the formaldehyde (99.9%) exists as methanediol in an equilibrium with free (0.1%) formaldehyde (Fox et al., 1985). Thus, formaldehyde is first hydrated in nasal mucus to form methanediol, which subsequently interacts with the nasal mucociliary apparatus (Priha et al., 1996; Bogdanffy et al., 1986). Physical-organic chemistry studies of the reaction of formaldehyde with amines (and presumably other biological nucleophiles) have conclusively demonstrated that the unhydrated or free form of formaldehyde, but not the hydrated form or methanediol is the reactive species (Abrams and Kallen, 1976). Methanediol is either transported to the underlying tissue (presumably by diffusion) or it is removed within nasal mucus by convective flow and subsequent ingestion. Schlosser (1999) estimated that 22–42% of the absorbed formaldehyde in rodents is removed by mucus flow.

Airborne pollutants and reactive gases have been shown to decrease mucus flow rates in several animal models (as reviewed in (Wolff, 1986)). Degradation in the continuity or function of this mucociliary apparatus can impair clearance of inhaled pollutants at the portal of entry. For example, (Morgan et al., 1983) have shown that a single exposure of 18.45 mg/m^3^ formaldehyde in Fischer rats causes mucostasis (cessation or severe slowing of mucus flow) in several regions of the nasoturbinates. Exposure (6 hours/day for 1–9 days) results in ciliastasis (loss of ciliary activity) occurring with greater frequency and across more regions of the nasoturbinates in subsequent days of exposure. Thus, continued exposure would be expected to result in an increased uptake, as well as an altered deposition of inhaled formaldehyde within the URT tissue. Further, (Morgan et al., 1986c) also reported that rats exposed 6 hours daily for 3 weeks showed an increase in mucostasis extending from anterior to posterior regions at the 18.45 mg/m^3^ dose; however, at lower doses (0.6–7.4 mg/m^3^) the effect was either undetectable or less severe. In addition, (Morgan et al., 1986c) showed an increase in mucus flow at lower concentrations after 4 days of exposure, but not after 6 days to 0.6 mg/m^3^ formaldehyde. Thus, there are some uncertainties regarding the occurrence of mucostasis at lower concentrations of formaldehyde exposure.

In addition, as methanediol and free formaldehyde are transported through the mucociliary apparatus, the free formaldehyde is known to bind to soluble proteins such as albumin in the nasal mucus (Bogdanffy et al., 1987). Similarly, the nasal lining fluid contains antioxidants, including the thiol GSH with which formaldehyde is known to interact, likely eliciting a transient GSH depletion during and following formaldehyde exposure. However, it is unclear to what extent inhaled formaldehyde interacts with soluble and insoluble factors within the mucociliary layer and whether reactive byproducts may be formed by these interactions. Importantly, endogenous formaldehyde produced during normal cellular metabolism is unlikely to be present at appreciable levels in the mucus, and thus, would not be expected to participate in similar reactions. Interactions with soluble proteins are expected to further reduce the amount of formaldehyde available to react with cellular materials. As such, alterations in the levels of soluble proteins within the mucus could substantially affect tissue uptake.

#### Formaldehyde diffusion into the epithelial cell layer

The less reactive methanediol is better able to penetrate tissues, while the free formaldehyde reacts with macromolecules. However, when the free formaldehyde (≈0.1%) is used up, a fraction of methanediol (from the 99.9%) will convert to free formaldehyde so that the equilibrium of methanediol with free formaldehyde (i.e., 99.9:0.1 ratio) is maintained in the aqueous media (Fox et al., 1985). However, several uncertainties exist regarding the transition of inhaled formaldehyde from the mucociliary layer to the underlying epithelium. Although direct experimental evidence is lacking, the biochemical properties of formaldehyde make it likely that inhaled formaldehyde (in the hydrated or anhydrated form) undergoes passive transport, via simple diffusion, across biological membranes. Thus, higher extracellular formaldehyde levels would be expected to result in increased diffusion into the cell owing to the concentration gradient formed. However, this concentration gradient may be affected by endogenous formaldehyde levels because in humans, as in other animals, formaldehyde is an essential metabolic intermediate in all cells (Thompson et al., 2009).

#### Enzymatic metabolism of formaldehyde within cells of the URT

Formaldehyde, either from exogenous sources (inhaled air) or endogenous sources (enzymatic and nonenzymatic mechanisms as well as that released endogenously from metabolism of xenobiotics), can be metabolized by several different enzyme pathways. Based on studies of endogenous formaldehyde and in vitro enzyme inhibition experiments (Teng et al., 2001), and as summarized in Figure C-2, formaldehyde has been shown to be predominantly metabolized to formate by GSH-dependent class III alcohol dehydrogenase (ADH3; also described as formaldehyde dehydrogenase or FDH) and by a minor pathway involving mitochondrial aldehyde dehydrogenase 2 (ALDH2) which is GSH-independent. Catalase may also be involved, to a minor extent, in oxidizing formaldehyde, especially under conditions when hydrogen peroxide is formed (Uotila and Koivusalo, 1974).

Figure C-2 Metabolism of formaldehyde

Abbreviations: CO2, carbon dioxide; DPX, DNA-protein crosslinks; GSH, glutathione; H_2_O, water; H_2_O_2_, hydrogen peroxide; HMGSH, hydroxymethylglutathione; NAD^+^, nicotinamide adenine dinucleotide (oxidized); NADH, nicotinamide adenine dinucleotide (reduced); Na^+^HCOO^−^, sodium formate. Enzymes: a, alcohol dehydrogenase-3 (ADH3); b, aldehyde dehydrogenase 2 (ALDH2); c, catalase; d, S-formyl-GSH hydrolase.

Adapted from NTP (2010).

Both ADH3 and ALDH2 enzymes have been found across different species and in a broad range of tissues, including the nasal mucosa (Reviewed (Thompson et al., 2009)). In rodents, both ADH3 and ALDH2 exhibit region-specific differences in the nose, in that the specific activity of ADH3 is two times higher in the olfactory mucosa than in respiratory mucosa, while the specific activity of ALDH2 is 5–8 times higher in respiratory than in olfactory tissue (Casanova-Schmitz et al., 1984a; Bogdanffy et al., 1986). In rats, higher levels of ADH3 activity have been reported in the cytoplasm of the respiratory and olfactory epithelial cells and in the nuclei of olfactory sensory cells, as compared to other regions of the nasal mucosa (Keller et al., 1990). These enzymes are enriched in the nasal tissues presumably to protect the underlying tissues against respired toxicants. This highlights a significant barrier to the penetration of inhaled formaldehyde beyond the respiratory epithelium and a means by which these same cells can rapidly metabolize formaldehyde produced endogenously within the cell (Uotila and Koivusalo, 1974).

The ADH3-mediated pathway of formaldehyde oxidation involves a two-step enzymatic reaction but is preceded by the rapid and reversible nonenzymatic binding of formaldehyde to GSH, which results in the formation of S-hydroxymethylglutathione (HMGSH) or the glutathione hemiacetal adduct. In the first of a two-step enzymatic reaction, ADH3 converts HMGSH to S-formylglutathione (S-formyl-GSH) in the presence of the co-factor, nicotinamide adenine dinucleotide (NAD^+^). In the second step, another enzyme S-formyl-GSH-hydrolase converts S-formyl-GSH to formate with the concomitant release of free GSH. Under physiological conditions, cellular NAD^+^ levels are two orders of magnitude higher than NADH (reduced form of NAD^+^) and intracellular GSH levels are high enough (in millimolar concentrations) to favor rapid oxidation of HMGSH to formate (Svensson et al., 1999; Meister and Anderson, 1983). Because of this rapid metabolism, formaldehyde is likely to have a short half-life in biological systems. As previously mentioned, and given the importance of this major detoxification pathway, individual variations in GSH levels within the nasal mucosa are of particular importance in formaldehyde metabolism.

ADH3 shows comparable kinetics across rats and humans. As shown in Table C-3, the affinity (K_m_) of purified human liver ADH3 for HMGSH is 6.5 µM (Uotila and Koivusalo, 1974) and 4.5 mM for rat liver (Casanova-Schmitz and Heck, 1983). (Hedberg et al., 2000) demonstrated that the kinetics of ADH3 in human buccal tissue lysates are in close agreement with those reported for purified human liver ADH3 (Uotila and Koivusalo, 1974). This is comparable to the rat respiratory and olfactory mucosal K_m_ values in the presence of GSH as well as the K_m_ of ADH3 from the rat liver soluble fraction (2.6 µM) (Casanova-Schmitz et al., 1984a). In contrast, the affinity of ALDH2, presumably in the absence of GSH, is several-fold lower than ADH3 (Siew et al., 1976). Thus, at lower concentrations of formaldehyde ADH3 is the dominant formaldehyde detoxification pathway. The K_m_ of ADH3 is in close agreement across species and tissue types, including the nasal mucosa, all of which exhibit similar responses to GSH depletion (i.e., in the absence of GSH, ALDH family members oxidize formaldehyde, which is associated with mitochondrial ALDH2). Both ADH3- and ALDH2-mediated pathways oxidize formaldehyde to formic acid (formate). ADH3 is also known to catalyze the NADP-dependent reduction of the endogenous nitrosylating agent S-nitrosoglutathione (GSNO) and is also referred to as S-nitrosoglutathione reductase (GSNOR) (Jensen et al., 1998).

Table C-3 ADH3 kinetics in human and rat tissue samples and cultured cells

Source | Km(μM) | Vmax (nmol/mg protein x min) | References
Purified human liver ADH3 | 6.5 | 2.77 ± 0.12 | Uotila and Koivusalo (1974)
Rat respiratory mucosal homogenate (+GSH) | 2.6 ± 2.6 | 0.90 ± 0.24 | Casanova-Schmitz et al. (1984a)
Rat respiratory mucosal homogenate (− GSH) | 481 ± 88 | 4.07 ± 0.35 | Casanova-Schmitz et al. (1984a)
Rat olfactory mucosal homogenate (+GSH) | 2.6 ± 0.5 | 1.77 ± 0.12 | Casanova-Schmitz et al. (1984a)
Rat olfactory mucosal homogenate (− GSH) | 647 ± 43 | 4.39 ± 0.14 | Casanova-Schmitz et al. (1984a)
Rat liver (+ GSH)^a^ | 4.5 ± 1.9^a^ | 2.0 ± 0.3 | Casanova-Schmitz et al. (1984a)
Human buccal tissue (+ GSH) | 11 ± 2 | 2.9 ± 0.6 | Hedberg et al. (2000)
Human buccal tissue (− GSH) | 360 ± 90 | 1.2 ± 0.7 | Hedberg et al. (2000)

ADH3 = alcohol dehydrogenase 3; K_m_ = substrate concentration at which half of the maximum velocity is achieved; V_max_ = maximum reaction velocity at which all enzymes becore saturated; GSH = glutathione.

a Soluble fraction of rat liver homogenate.

Formate can undergo three possible outcomes: (1) enter the one-carbon pool for use in the synthesis of DNA and proteins (aka “metabolic incorporation”), (2) become further oxidized to CO_2_ and eliminated in exhaled air, or (3) be excreted in urine (see Figure C-2).

##### One-carbon metabolism

As summarized in Figure C-3, tetrahydrofolate (THF)-mediated eukaryotic one-carbon (1C) metabolism involves an inter-connected network which is highly compartmentalized between the cytosol, mitochondria, and nucleus (Reviewed in (Tibbetts and Appling, 2010)). A majority of the 1C metabolism takes place in the mitochondria followed by the cytosol and nucleus. In cytoplasmic 1C metabolism, de novo synthesis of purines and thymidylate, and remethylation of homocysteine to methionine takes place. 1C metabolism in the mitochondrial compartment involves formylation of methionyl-tRNA, and oxidation of one-carbon donors, such as serine, glycine, sarcosine, and dimethylglycine (DMG). In addition, mitochondria contribute 1C units for cytoplasmic 1C metabolism in the form of formate. The mitochondrial and cytoplasmic pathways are connected by serine, glycine and formate which are the 1C donors. The nuclear compartment of 1C metabolism predominantly provides de novo synthesis of dTMP from dUMP.

Some of the steps in both cytosolic and mitochondrial 1C metabolism are common. Formate, formed from the metabolism of formaldehyde, enters the 1C pool and is either oxidized to CO_2_ and eliminated in exhaled breath or is used in protein and DNA synthesis. As shown in Figure C-3, formate is combined with THF whereby its 1C group is transferred to THF forming 10-formyl-THF (10-CHO-THF), mediated by the enzyme 10-HCO-THF-synthetase. The 10-CHO-THF is then oxidized by CHO-THF dehydrogenase to CO_2_ and H_2_O and eliminated in exhaled breath, with the release of THF which can be reused for binding with formic acid. Alternatively, 10-CHO-THF can also be converted through two-steps of reversible reactions to 5,10-methenyl-THF (CH^+^-THF) to 5,10-methylene-THF (CH_2_-THF). Serine, derived from glycolytic intermediates, is the main source of 1C units. Serine combined with THF is converted reversibly by the enzyme serine hydroxymethyl transferase (SHMT) to glycine and CH_2_-THF. Further, the enzyme methylene tetrahydrofolate reductase (MTHFR) converts CH_2_-THF to 5-methyl-THF (CH_3_-THF). The 1C metabolism products - CH_2_-THF and CH_3_-THF utilize their one-carbon units, respectively, in DNA (dTMP) and protein (methionine) biosynthetic pathways (metabolic incorporation).

Figure C-3 Compartmentalization of mammalian one-carbon metabolism

The end products, donors, and activated units carried by tetrahydrofolate (THF) of the 1C metabolism are shown in red, blue, and green, respectively. Note that reactions 1–4 are common in both the cytoplasmic and mitochondrial (m) compartments, while reactions 4 and 10 are present in the nucleus (n). Enzymes catalyzing the reactions: 1: 10-formyl-THF synthetase; 2: 5,10-methenyl-THF (CH+-THF) cyclohydrolase; 3: 5,10-methylene-THF (CH_2_-THF) dehydrogenase; 4, 4n, and 4m: serine hydroxymethyltransferase (SHMT); 5: glycine cleavage system; 6: 5,10-methylene-THF reductase; 7: methionine synthase; 8: dimethylglycine dehydrogenase (DMGDH); 9: sarcosine dehydrogenase (SDH); 10 and 10n: thymidylate synthase; 11: 10-formyl-THF dehydrogenase (only the mitochondrial activity of this enzyme is shown, but it has been reported in both compartments in mammals); 12: methionyl-tRNA formyltransferase; 13: dihydrofolate (DHF) reductase; 14: betaine-homocysteine methyltransferase. Abbreviations: AdoHcy, S-adenosylhomocysteine; AdoMet, S-adenosylmethionine; Hcy, homocysteine.

Source: Tibbetts and Appling (2010).

The rate of formate metabolism depends on the availability of dietary folic acid, which is the main source of THF. It is also important to note that levels of folate intermediates and folate-dependent enzymes show some differences in rats and primates (see Table C-4).

Table C-4 Levels of folate intermediates, activity of folate-dependent enzymes, and the rate of oxidation of formate in the liver of various species

Folate intermediate/folate-dependent enzyme | Rat | Monkey | Human
10-formyl-THF (nmoles/g of liver) | 4.6 ± 1.3 | 10.5 ± 0.8 | 3.3 ± 0.5
Tetrahydrofolate (nmoles/g of liver) | 11.4 ± 0.8 | 7.4 ± 0.8 | 6.5 ± 0.3
5-CH_3_-THF (nmoles/g of liver) | 9.3 ± 0.6 | 7.6 ± 1.1 | 6.0 ± 0.7
10-formyl-THF synthetase (nmoles of product/min/mg protein) | 65.9 ± 0.0 | 142 ± 16 | 75.0 ± 8.7
10-formyl-THF dehydrogenase (nmoles of product/min/mg protein) | 88.3 ± 1.7 | 33.0 ± 4.0 | 23.0 ± 2.2
5,10-CH_2_-THF reductase (nmoles of product/min/mg protein) | 1.21 ± 0.07 | 0.22 ± 0.02 | 0.42 ± 0.07
Serine hydroxymethyl transferase (nmoles of product/min/mg protein) | 10.8 ± 0.6 | 17.1 ± 9.7 | 18.5 ± 0.7
Dihydrofolate reductase (nmoles of product/min/mg protein) | 19.8 ± 1.3 | 4.1 ± 0.7 | 0.74 ± 0.17
Methionine synthase (nmoles of product/min/mg protein) | 0.09 ± 0.007 | 0.09 ± 0.012 | 0.10 ± 0.008
Rate of formate oxidation (mg/kg/hr) | 78 | 40 | 0

Source: Skrzydlewska (2003)

THF, tetrahydrofolate; CH_2_-THF, methylene tetrahydrofolate.

As shown in Table C-4, the normal hepatic THF levels of monkeys and humans are 1.5 and 1.75-fold lower than the levels in rats. Also, the levels of 10-formyl-THF-dehydrogenase levels are 2.67- and 3.83-fold lower in the livers of monkeys and humans, respectively, compared to the levels in rat liver, which might cause an accumulation of formate in primates since there is decreased oxidation of formate to CO_2_. Thus, primates oxidize formate less efficiently than rats (Skrzydlewska, 2003).

#### Interaction of formaldehyde with cellular macromolecules in the URT

As mentioned earlier, it has been shown that “free” formaldehyde (i.e., the 0.1% of total formaldehyde that does not exist in the form of methanediol) reacts with macromolecules (Abrams and Kallen, 1976). However, it is unclear whether methanediol in certain hydrophobic matrices (e.g., biological membranes, etc.) could be converted to a more reactive form and available to interact with cellular materials. Inhaled formaldehyde interacts at the portal of entry with the nasal passage macromolecules, and these interactions can be either noncovalent (reversible) or covalent (irreversible).

#### Noncovalent interactions

Formaldehyde is reversibly bound to GSH and THF in cells forming the glutathione hemithioacetal adduct or hydroxymethylglutathione (HMGSH) adduct and 5, 10-CH_2_-THF adducts. Levels of the cellular antioxidant glutathione are abundant in the cell ≈5 mM with which formaldehyde readily forms the hemiacetal adduct. The dissociation constant for the hemiacetal and CH_2_-THF adducts are approximately 1.5 mM (Uotila and Koivusalo, 1974) and ≈30 µM, respectively (Kallen and Jencks, 1966a, b). Based on in vitro experiments formaldehyde has been shown to reversibly bind to human and rat nasal mucus, in particular the fraction containing albumin (Bogdanffy et al., 1987).

#### Covalent binding

Formaldehyde covalently binds to protein and DNA, forming protein adducts, DNA adducts, DNA-protein crosslinks (DPX), and DNA-DNA crosslinks (DDX). A complication that has been explored in some of these studies is that inhaled formaldehyde can also be metabolized and incorporated into DNA and proteins via the 1C pool.

##### Protein adducts

Formaldehyde has been shown to bind to histones and chromatin forming N^6^-formyllysine (Edrissi et al., 2013a) and a major source of this adduct has been shown to result from endogenous formaldehyde. Further, in rats exposed to various inhalation concentrations of ^1^[2]^^C-labeled formaldehyde (0.9–11.2 mg/m^3^), a concentration-dependent increase in ^13^C-labeled N^6^-formyllysine, which was distinguished from endogenous N^6^-formyllysine, was detectable in the total proteins as well as in protein fractions from different cellular compartments (cytoplasmic, membrane, and nuclear) of the respiratory epithelium (Edrissi et al., 2013a).

#### DNA-protein Crosslinks

Formaldehyde-induced DNA-protein crosslinking occurs predominantly between the epsilon-amino groups of lysine, especially at the N-terminus of histones, and exocyclic amino groups of DNA (Lu et al., 2008). Several analytical methods including radiolabeled formaldehyde have been used to evaluate DPX formation in experimental animals. Earlier experiments have shown that inhalation of F344 rats to 2.46–36.93 mg/m^3^ of ^14^C-formaldehyde (6 hours/day, 2 days) caused a significant increase in the radioactivity of interfacial (IF) DNA^3^, representing DPX, observed in tissue homogenates from respiratory but not olfactory epithelium at ≥ 7.38 mg/m^3^ (Casanova-Schmitz and Heck, 1983). Formaldehyde-induced DPX levels have been shown to have concentration-dependence in both monkeys (0.86 to 7.37 mg/m^3^) (Casanova et al., 1991) and rats (0.37–12.1 mg/m^3^) (Casanova et al., 1989; Casanova et al., 1994). In both rodents and monkeys there was a nonlinear concentration-response for DPX formation, which has been attributed to saturation of detoxification enzymes at high concentrations (Casanova et al., 1989; Casanova et al., 1991). In monkeys, the DPX distribution pattern in the nasal passages following formaldehyde inhalation was in the order of middle turbinates > anterior lateral wall/septum > maxillary sinuses and lungs (Casanova et al., 1991), which corresponded to the location and proliferative response. In rats the DPX distribution pattern was in the order of lateral meatus > medial and posterior meatus (Casanova et al., 1994), which corresponded to the high and low tumor incidence sites in the respiratory tract (Monticello et al., 1989). This is possibly due to the differences in the anatomy of nasal passages and breathing patterns of these two species.

Recently, (Lai et al., 2016) developed a method that distinguishes deoxyguanosine-methyl-cysteine (dG-Me-Cys), a DPX formed with exogenous formaldehyde, from that formed with endogenous formaldehyde (see Table C-5). In monkeys exposed to 7.4 mg/m^3^ of ^13^C-labeled formaldehyde for 2 days, both exogenous and endogenous DPXs were detectable, with the levels of exogenous DPXs being 2.8-fold less than the endogenous DPX adducts. In contrast, only endogenous DPXs were detectable in air-exposed monkeys. In rats, a higher dose of 18.5 mg/m^3^ formaldehyde exposure for 1, 2, or 4 days was tested. DPX levels in nasal tissues were detected and were comparable for endogenous and exogenous formaldehyde among rats exposed 1 or 2 days, but at 4 days, DPX levels from exogenous formaldehyde had increased 5-fold above those from endogenous formaldehyde. Similarly, DPX levels from exogenous formaldehyde increased between 7 days and 28 days in rats exposed to 2.5 mg/m^3^.

Using in vitro studies, (Yu et al., 2015b) have shown that DPX such as, dG-CH_2_-cysteine or dG-CH_2_-GSH can undergo hydrolytic degradation to give rise to hm-dG monoadducts under physiological pH and temperature conditions. These results provide a mechanism which explains why formaldehyde-induced DPX are removed within 12.5–24 hours in cultured human epithelial cell lines (Quievryn and Zhitkovich, 2000) and lymphoblasts (Craft et al., 1987). However, the in vivo studies by Lai (2016) did not replicate this phenomenon. These more precise studies showed that in rats exposed to 2.5 mg/m^3^ labeled formaldehyde for 28 days, at 1-week postexposure, 87% of the exogenous DPX were retained in the nasal tissues, suggesting a slow repair of these bulky adducts. The potential implications of this for dose-response modeling are discussed in Appendix D.2.2.

Table C-5 Summary of endogenous and exogenous DNA-protein crosslinks in nasal tissues of rats following inhalation exposure of ^13^CD_2_-labeled formaldehyde

Reference and design | Exposure and analysis | Exposure duration | CH_2_O conc. | Observations
Lai et al. (2016); Monkeys, cynomolgus; N = 4–6. | 0 (air control) or 7.4 mg/m^3^ [^13^CD_2_]-CH_2_O from PFA by inhalation; 6 hrs/d; for 2 d; whole-body exposure; nasal tissue collected; DNA extracted with DNAzol reagent, dG-Me-Cys purified on HPLC and analyzed by nano-LC/ESI/MS-MS. | | (mg/m^3^) | Endogenous adducts | Exogenous adducts
Lai et al. (2016); Monkeys, cynomolgus; N = 4–6. | | | (mg/m^3^) | dG-Me-Cys/10^8^ dG
Lai et al. (2016); Monkeys, cynomolgus; N = 4–6. | | 2 d | 0 | 3.59 ± 1.01 | ND
Lai et al. (2016); Monkeys, cynomolgus; N = 4–6. | | 2 d | 7.4 | 3.76 ± 1.50 | 1.36 ± 0.20
Lai et al. (2016); Rats, F344; N = 4–6. | 0 (air control) or 18.5 mg/m^3^ [^13^CD_2_]−CH_2_O from PFA by inhalation; 6 hrs/d; for 1, 2, or 4 d; whole-body exposure; nasal tissue collected; DNA extracted with DNAzol reagent, dG-Me-Cys purified on HPLC and analyzed by nano-LC/ESI/MS-MS. | Exposure Duration | (mg/m^3^) | Endogenous adducts | Exogenous adducts
Lai et al. (2016); Rats, F344; N = 4–6. | | | | dG-Me-Cys/10^8^ dG
Lai et al. (2016); Rats, F344; N = 4–6. | | 4 d | 0 | 6.50 ± 0.30 | ND
Lai et al. (2016); Rats, F344; N = 4–6. | | 1 d | 18.5 | 4.42 ± 1.10 | 5.52 ± 0.80
Lai et al. (2016); Rats, F344; N = 4–6. | | 2 d | 18.5 | 4.28 ± 2.34 | 4.69 ± 1.76
Lai et al. (2016); Rats, F344; N = 4–6. | | 4 d | 18.5 | 3.67 ± 0.80 | 18.18 ± 7.23
Lai et al. (2016); Rats, F344; N = 4–6. | Rats, inhalation exposure to 2.5 mg/m^3^ CH_2_O for 7 or 28 d and allowed to recover for 1 or 7 d PE. Nasal tissue collected and DNA extracted at the given time points and analyzed for dG-Me-Cys adducts as above. | Exposure Duration | (mg/m^3^) | Endogenous adducts | Exogenous adducts
Lai et al. (2016); Rats, F344; N = 4–6. | | Exposure Duration | (mg/m^3^) | dG-Me-Cys/10^8^ dG
Lai et al. (2016); Rats, F344; N = 4–6. | | 7 d | 2.5 | 4.78 ± 0.64 | 0.96 ± 0.17
Lai et al. (2016); Rats, F344; N = 4–6. | | 28 d | 2.5 | 4.51 ± 1.48 | 2.46 ± 0.44
Lai et al. (2016); Rats, F344; N = 4–6. | | 28 d + 1 d PE | 2.5 | 3.78 ± 0.69 | 2.12 ± 1.00
Lai et al. (2016); Rats, F344; N = 4–6. | | 28 d + 7 d PE | 2.5 | 3.51 ± 0.16 | 2.14 ± 1.02

Abbreviations: PFA, paraformaldehyde; LC, liquid chromatography; MS, mass spectrometry; HPLC, high performance liquid chromatography; CH2O, formaldehyde; DPX, DNA-protein crosslinks; dG-Me-Cys, deoxyguanosine-methyl-cysteine; PBMC, peripheral blood mononuclear cell; ESI, electron spray ionization; PE, post-exposure; D2, deuterium.

#### Distinguishing covalent binding of formaldehyde from metabolic incorporation

Three studies from the same research group addressed the issues of differentiating covalently bound (i.e., DPX formation) versus metabolically incorporated formaldehyde in rats exposed to formaldehyde by inhalation (Casanova-Schmitz and Heck, 1983; Casanova-Schmitz et al., 1984b; Casanova and Heck, 1987).

Casanova-Schmitz et al. (1984b) used dual isotope labeling as a way to partially distinguish between covalent binding (DPX formation) and metabolic incorporation of formaldehyde. In this approach, male F344 rats were exposed to a mixture of ^3^H- and ^14^C-labeled formaldehyde for 6 hours at exposure concentrations ranging from 0.37–18.42 mg/m^3^, a day after exposure to nonradioactive formaldehyde with the same dose range. The IF DNA was extracted from respiratory and olfactory mucosa, and the ^3^H/^14^C ratios of different phases of DNA extraction (i.e., AQ DNA and IF DNA) were measured. It is important to note that formaldehyde loses the hydrogen atom during oxidation reactions (i.e., metabolic incorporation), but not during covalent binding to DNA. Therefore, the ^3^H/^14^C ratio in a sample that contains adducts and crosslinks should be higher than in a sample that primarily contains DNA with metabolically incorporated formaldehyde.

Figure C-4 Metabolic incorporation and covalent binding of formaldehyde in rat respiratory tract

^3^H/^14^C ratios in macromolecular extracts from rat respiratory mucosa (A) and olfactory mucosa (B) following 6-hour exposure to ^14^C- and ^3^H-labeled formaldehyde (0.3, 2, 6, 10, and 15 ppm, corresponding to 0.37, 2.46, 7.38, 12.3, 18.42 mg/m^3^, respectively).

Source: Adapted from Casanova-Schmitz et al. (1984b)

As seen in panel A of Figure C-4, (Casanova-Schmitz et al., 1984b) report that IF DNA from nasal respiratory mucosa has a significantly higher ^3^H/^14^C ratio (Y-axis) than the aqueous phase (AQ) DNA, with a nonlinear dose response of IF DNA at exposure concentrations equal to or greater than 2.46 mg/m^3^. These data suggest that IF DNA has significantly more ^3^H, a phenomenon likely explained by additional ^3^H-formaldehyde molecules present as DPXs prior to DNA extraction. These crosslinks were due to exogenous formaldehyde that could be attributed to DPX. The ^3^H/^14^C ratio was linearly increased for the organic fraction, suggesting covalent binding of formaldehyde to respiratory mucosa proteins. In contrast, olfactory mucosa did not show increased ^3^H/^14^C ratio in the IF DNA or AQ DNA or proteins phase as a function of formaldehyde concentration (panel B, see Figure C-4). In total, these data suggest that the radiolabeling observed following formaldehyde exposure in rats results from both covalent binding and metabolic incorporation in the nasal mucosa, but not the olfactory mucosa (Casanovaschmitz et al., 1984). The respiratory mucosa from unexposed rats appears to contain 15% of DNA as IF DNA (Casanova-Schmitz and Heck, 1983), possibly as endogenous DPX.

#### DNA monoadducts

Another form of formaldehyde-induced covalent DNA modifications is hydoxymethyl-DNA (hm-DNA) adducts or DNA monoadducts. Five studies conducted in one laboratory used ^13^CD_2_-formaldehyde in experimental rats and monkeys coupled with an LC/MS approach to distinguish hm-DNA adducts formed by endogenous and exogenous formaldehyde (Yu et al., 2015b; Moeller et al., 2011; Lu et al., 2010a; Lu et al., 2011), as summarized in Table C-6. In this method, hm-DNA adducts formed by exogenous ^13^CD_2_-formaldehyde are distinguished from unlabeled endogenous hm-DNA adducts based on the differences in their typical m/z ratio (Lu et al., 2012b). As shown in Table C-6, both exogenous and endogenous N^2^-hydroxymethyl-deoxyguanosine (N^2^-hm-dG) adducts were detected in nasal tissues of cynomolgus monkeys exposed to 2.34 or 7.5 mg/m^3^ ^13^CD_2_-formaldehyde for 2 days, and across several rat studies testing exposures ranging from 0.9–18.7 mg/m^3^ formaldehyde for several hours up to 28 days (Yu et al., 2015a; Yu et al., 2015b; Lu et al., 2010a; Lu et al., 2011). Notably, however, these studies demonstrate that the levels of endogenous N^2^-hm-dG adducts were several folds higher than corresponding exogenous adducts in nasal tissue.

While these studies provide the first insights into the relationship between endogenous and exogenous DNA monoadducts, further study may help to clarify some remaining uncertainties. For example, the potential involvement of different types of DNA monoadducts, as well as their specific toxicodynamic roles (e.g., for cancer development), remain poorly understood. Of the studies which used inhalation exposure to ^13^C-labeled formaldehyde, only (Lu et al., 2010a) quantified other adduct types; interestingly, while the authors detected ^13^CD_2_-labeled N^2^-hm-dG adducts and dG-CH_2_-dG crosslinks, they did not detect N^6^-hydroxymethyl-deoxyadenosine (N^6^-hm-dA) adducts in the nasal epithelium of rats exposed for 1 or 5 days (12.3 mg/m^3^) to exogenous formaldehyde. However, the same group reported the formation of both N^2^-hm-dG (most of the tissues) and N^6^-hm-dA monoadducts (only in bone marrow) in rats that were dosed by gavage with ^13^C-labeled methanol, which is a precursor of formaldehyde (Lu et al., 2012b). Similarly, a different research group reported that rats dosed subcutaneously with nitrosamines (Wang et al., 2007b), which are precursors to formaldehyde, and smokers (Wang et al., 2009a) both exhibit N^6^-hm-dA monoadducts in peripheral tissues. Thus, additional sensitive evaluations of dA monoadducts, particularly following longer term formaldehyde exposure and preferably in humans, may be informative. Also of interest, it is important to keep in mind that the experiments conducted to date involve comparisons of endogenous adduct levels, which would represent steady-state formaldehyde levels after having built up over time from the continuous presence of endogenous formaldehyde, to exogenous adduct levels resulting from short-term and/ or episodic (e.g., 6 hours/day) exposures. As an illustration, with exogenous exposure for 6-hourr/day, multiple weeks or longer could be needed to reach steady-state levels, and, even so, those levels could be roughly expected to be four-fold lower than if a continuous (24 hours/day) exogenous exposure occurred at the same concentration. The recent study by (Yu et al., 2015b) begins to address this, noting that “quasi-steady-state” levels appear to be nearing after 6hr-day exposure to 2.46 mg/m^3^ formaldehyde for 28 days; however, exogenous adducts were still substantially increased with 28 days, as compared to 21 days of exposure, and exogenous adduct levels reached ≈37% of endogenous adduct levels (1.05 versus 2.82 adducts/10^7^ dG, in contrast to the ≈14% observed after 7 days of exposure) under this scenario. Considering these data at 2.46 mg/m^3^, the comparability of endogenous versus exogenous adducts relevant to lifetime exposure scenarios would be informed by additional studies incorporating a range of experiments and formaldehyde concentrations that span short, episodic exposures to more constant, long-term exposures.

Table C-6 Summary of endogenous and exogenous DNA monoadducts in nasal tissue of monkeys and rats following inhalation exposure of ^13^CD_2_-labeled formaldehyde

Reference and design | Exposure and analysis^a^ | Portal of entry tissues | CH_2_O exposure conc. (mg/m^3^) | Observations
Reference and design | Exposure and analysis^a^ | Portal of entry tissues | CH_2_O exposure conc. (mg/m^3^) | Endogenous adducts | Exogenous adducts
| | | | N^2^-hm-dG/10^7^dG
Moeller et al. (2011); Monkeys, cynomolgus; n =3 | 2.34 or 7.5 mg/m^3^ [^13^CD_2_]-CH_2_O; 6 hrs/d; for 2 d (whole-body exposure); sacrificed immediately after exposure; tissues collected. | Nasal maxilloturbinates | 2.34 | 2.50 ± 0.40 | 0.26 ± 0.04
Moeller et al. (2011); Monkeys, cynomolgus; n =3 | 2.34 or 7.5 mg/m^3^ [^13^CD_2_]-CH_2_O; 6 hrs/d; for 2 d (whole-body exposure); sacrificed immediately after exposure; tissues collected. | Nasal maxilloturbinates | 7.5 | 2.05 ± 0.54 | 0.41 ± 0.05
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | 0 (air control), 2.4 or 7.5 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; nose-only exposure; 6 hrs/d for consecutive d; Sacrificed immediately after exposure; maxilloturbinates (Animal #1) and all other nasal tissues (Animal #2) were collected. | Nasal maxilloturbinates | 2.4 | 2.50 ± 0.44 | 0.26 ± 0.04
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal maxilloturbinates | 7.5 | 2.05 ± 0.54 | 0.41 ± 0.05
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal dorsal mucosa | 0 | 3.81 ± 1.19 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal dorsal mucosa | 7.5 | 3.62 ± 1.28 | 0.40 ± 0.07
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal nasopharynx | 0 | 3.48 ± 0.53 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal nasopharynx | 7.5 | 3.62 ± 1.34 | 0.33 ± 0.10
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal septum | 0 | 3.75 ± 0.32 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal septum | 7.5 | 3.56 ± 0.69 | 0.39 ± 0.15
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal anterior maxillary | 0 | 4.21 ± 0.53 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal anterior maxillary | 7.5 | 3.80 ± 0.91 | 0.34 ± 0.12
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal posterior maxillary | 0 | 3.95 ± 0.74 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Nasal posterior maxillary | 7.5 | 3.46 ± 1.05 | 0.36 ± 0.16
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Trachea carina | 0 | 2.69 ± 0.95 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Trachea carina | 7.5 | 2.33 ± 1.12 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Trachea proxima | 0 | 2.35 ± 1.05 | ND
Yu et al. (2015b); Monkeys, cynomolgus; n = 4 | | Trachea proxima | 7.5 | 2.35 ± 1.05 | nd
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | 1-d | 2.63 ± 0.73 | 1.28 ± 0.49
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | 5-d | 2.84 ± 1.13 | 2.43 ± 0.78
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | | N^6^-hm-dA/10^7^ dA
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | 1-d | 3.95 ± 0.26 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | 5-d | 3.61 ± 0.95 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | | dG-CH_2_-dG/10^7^ dG
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | 1-d | 0.17 ± 0.05 | 0.14 ± 0.0
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.28 mg/m^3^ [^13^CD_2_]−CH_2_O generated from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure; tissues collected. | Nasal tissue^b,c^ | 5-d | 0.18 ± 0.06 | 0.26 ± 0.07
Lu et al. (2011); Rats, Fischer; n = 5–6 | [13CD2]−CH2O from [13CD2]PFA; 6 hrs, nose-only exposure; Sacrificed immediately after exposure; tissue collected. | Nasal tissue | | N^2^-hm-dG adducts/10^7^ dG
Lu et al. (2011); Rats, Fischer; n = 5–6 | [13CD2]−CH2O from [13CD2]PFA; 6 hrs, nose-only exposure; Sacrificed immediately after exposure; tissue collected. | Nasal tissue | 0.9 ± 0.25 | 3.62 ± 1.33 | 0.039 ±0.019
Lu et al. (2011); Rats, Fischer; n = 5–6 | [13CD2]−CH2O from [13CD2]PFA; 6 hrs, nose-only exposure; Sacrificed immediately after exposure; tissue collected. | Nasal tissue | 2.5 ± 0.12 | 6.09 ± 3.03 | 0.19 ± 0.08
Lu et al. (2011); Rats, Fischer; n = 5–6 | [13CD2]−CH2O from [13CD2]PFA; 6 hrs, nose-only exposure; Sacrificed immediately after exposure; tissue collected. | Nasal tissue | 7.1 ± 0.62 | 5.51 ± 1.06 | 1.04 ± 0.24
Lu et al. (2011); Rats, Fischer; n = 5–6 | [13CD2]−CH2O from [13CD2]PFA; 6 hrs, nose-only exposure; Sacrificed immediately after exposure; tissue collected. | Nasal tissue | 11.2 ± 2.71 | 3.41 ± 0.46 | 2.03 ± 0.43
Lu et al. (2011); Rats, Fischer; n = 5–6 | [13CD2]−CH2O from [13CD2]PFA; 6 hrs, nose-only exposure; Sacrificed immediately after exposure; tissue collected. | Nasal tissue | 18.7 ± 2.58 | 4.24 ± 0.92 | 11.15 ± 3.01
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | 0 (air control) or 2.46 mg/m^3^ [13CD2]CH2O from [13CD2]PFA; nose-only exposure; 6 hrs/d for 7, 14, 21, or 28 consecutive d; postexposure recovery for 6, 24, 72, and 168 hrs. Sacrificed immediately after exposure at indicated time points; tissues collected. | Nasal epithelium
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | Air control | 2.84 ± 0.54 | ND
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 7 d | 2.51 ± 0.63 | 0.35 ± 0.17
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 14 d | 3.09 ± 0.98 | 0.84 ± 0.17
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 21 d | 3.34 ± 1.06 | 0.95 ± 0.11
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 28 d | 2.82 ± 0.76 | 1.05 ± 0.16
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 6 hrs PE | 2.80 ± 0.58 | 0.83 ± 0.33
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 24 hrs PE | 2.98 ± 0.70 | 0.80 ± 0.46
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 72 hrs PE | 2.99 ± 0.63 | 0.63 ± 0.12
Yu et al. (2015b); Rats, Fischer, male; n = 8–9 | | Nasal epithelium | 168 hrs PE | 2.78 ± 0.48 | 0.67 ± 0.20

Abbreviations: CH2O, formaldehyde; D2, deuterium; MS, mass spectrometry; PE, postexposure; PFA, paraformaldehyde; ND, not detected; N2-hm-dG, N2-hydroxymethyl-deoxyguanine; N6-hm-dA, N6-hydroxymethyl-deoxyadenine; dG-CH2-dG, dG-dG crosslinks; UPLC, ultra-pressure liquid chromatography

a Tissue DNA was extracted, reduced with sodium cyanogen borohydride (NaCNBH3), digested, and analyzed by nano-UPLC-MS/MS.

b Nasal respiratory epithelium from the right and left sides of the nose and the septum.

c Exogenous N6-hmdA adducts were not detected in any tissues; exogenous N2-hm-dG and dG-dG crosslinks were detected only in nasal tissues.

Unknown contribution of potential interactions with other nasal mucosa elements

Formaldehyde is likely to interact with other components of the nasal mucosa depending on the concentration and duration of exposure. A small amount of inhaled formaldehyde, converted predominantly to methanediol, is expected to penetrate the epithelial cell layer, and react with the basement membrane or with constituents of the lamina propria, including components of the connective tissue/extracellular space, mucus gland components, lymphoid components, and vascular components. Andersen et al. (2008) examined gene expression in different tissue compartments of male F344 rats exposed to formaldehyde concentrations ranging from 0.9–18.5 mg/m^3^ by inhalation exposure. They reported that at low concentrations (0.9–2.5 mg/m^3^) formaldehyde is likely to react with the extracellular components of the cells at or near the cell membrane, while at higher doses (7.5–18.5 mg/m^3^) responses are observed in both extracellular and intracellular sites involving more genes in the response. The gene expression data from this study suggests the possibility for a potential interaction of formaldehyde with other nasal mucosa components.

#### Removal of inhaled formaldehyde from the POE

The main processes for removing inhaled formaldehyde from the URT involve clearance in the mucus and metabolism to formic acid. Formic acid can enter the 1C pool and may either be oxidized to CO_2_ or incorporated metabolically into nucleic acids and proteins carrying the 1C units through THF derivatives. Formate can also be absorbed into circulation, reach the kidneys, and be excreted in urine.

#### Summary of penetration, metabolism, and removal of inhaled formaldehyde within the URT tissue

In summary, as inhaled formaldehyde enters the URT it interacts with the mucociliary apparatus which is the first line of defense. In nasal mucus, most of the formaldehyde is rapidly converted to methanediol (≈99.9%) and a minor fraction remains as free formaldehyde (≈0.1%). Inhaled formaldehyde induces mucostasis and ciliastasis in rat nasal mucociliary apparatus extending from the anterior to posterior regions of the nasal cavity depending on the concentration and duration of exposure (Morgan et al., 1986a). However, as previously noted, uncertainties remain regarding the pattern of induced mucostasis, or the complete lack thereof, at low levels of formaldehyde exposure. Methanediol is assumed to be better able to penetrate tissues, while free formaldehyde reacts with macromolecules. It is assumed that equilibrium is reached rapidly, hence that the methanediol: free formaldehyde equilibrium ratio is maintained (Fox et al., 1985). However, uncertainties remain regarding the net impact of the transition of inhaled formaldehyde from the mucociliary layer to the underlying epithelium due to the presence of endogenous formaldehyde, which is a component of normal cellular metabolism. In the URT, formaldehyde is predominantly metabolized by glutathione-dependent class III alcohol dehydrogenase (ADH3) and by a minor pathway involving aldehyde dehydrogenase 2 (ALDH2) to formate. Formate can either enter the one-carbon pool leading to protein and nucleic acid synthesis or is further metabolized to CO_2_ and eliminated in expired air or excreted in urine unchanged.

Formaldehyde can interact with macromolecules either by noncovalently binding to GSH, THF, or albumin in nasal mucus or covalently forming DPX, DDX, hm-DNA adducts, or protein adducts. In rats and monkeys, formaldehyde exposure results in a concentration-dependent increase in DPX. Metabolic incorporation studies with ^14^C-formaldehyde have shown both covalent binding and metabolic incorporation in nasal tissues (Casanova-Schmitz et al., 1984b; Casanova and Heck, 1987). Distribution patterns in the nasal passages correspond to the tumor incidence locations in rats and to proliferative response patterns in both rats and monkeys. Hence, DPX has been used as a surrogate biomarker of exposure for risk assessment. Inhaled formaldehyde induces a concentration-dependent increase in N^2^-hm-dG adducts in the nasal passages of monkeys and rats. Recently, analytical methods have been developed that can distinguish N^2^-hm-dG adducts formed from exogenous sources from those formed from endogenous sources. Notably, endogenous N^2^-hm-dG adduct levels are much higher than exogenous monoadduct levels in animals because formaldehyde is known to be produced continuously during normal cellular metabolism. It has been suggested that N^2^-hm-dG adducts could be used as a marker of exposure in risk assessment. However, this use might be compromised by several methodological issues in the adduct isolation and analysis.

### C.1.4 Modifying Factors and Specific Uncertainties Regarding the Toxicokinetics of Inhaled Formaldehyde Within the POE

Many factors could influence the uptake and removal of inhaled formaldehyde at the POE. Distribution and tissue penetration of inhaled formaldehyde could both be significantly modified as a result of changes in environmental factors or tissue alterations induced by prolonged exposure. Similarly, metabolic detoxification of formaldehyde and clearance from the URT are dependent upon a number of cofactors and proteins that may be modified by changes to the environment or by prolonged exposure. Finally, modeling indicates that endogenous formaldehyde has the potential to impact the toxicokinetics of inhaled formaldehyde. This section will not include a description of every potential modifying factor but will attempt to highlight those interpreted to be most important or controversial, particularly those that may be essential to interpreting differences between experimental animals and humans.

#### Adjustments to account for reflex bradypnea in rodent studies

Reflex bradypnea (RB) is a protective reflex that allows rodents—but not humans—to significantly reduce their inhalation exposures to URT irritants such as formaldehyde. When an irritating concentration of formaldehyde triggers RB via the trigeminal nerve, rodents have an immediate decrease in respiratory rate and minute volume, and thus a marked decrease in formaldehyde exposure. Their RB persists until the exposure ends although the strength of the response in the initial minutes after exposure begins can be much stronger than later in the exposure. Kane and Alarie (1977) showed a maximal response in naïve mice of 13.7% decreased respiration rate from exposure to 0.55 ppm formaldehyde. This increased slightly to 15.6% in mice preexposed for 3 days. Consequently, a rodent study may not be health protective for humans unless the chamber concentrations or minute volume are adjusted to account for the rodents’ reduced formaldehyde exposure. However, existing models and dose-response analyses have not accounted for this effect.

Unfortunately, it is not known if or when rodents develop a tolerance to formaldehyde and resume normal breathing. Considering that Chang and Barrow (Chang and Barrow, 1984) reported that F-344 rats experienced RB throughout 10 days of formaldehyde exposure, it may be appropriate to adjust short-term rodent exposure concentrations to make them health protective for humans. Because a long-term RB study has never been performed for formaldehyde or any other URT irritant, there is no way of knowing whether similar adjustment is warranted for subchronic and/or chronic rodent studies. This is a significant data gap.

#### Modification due to effects of exposure on nasal mucosa function

Several events reported to occur after inhalation exposure to formaldehyde have the potential to modify the toxicokinetics of formaldehyde in the URT during subsequent exposure scenarios. Important among these factors are dynamic tissue remodeling, changes in mucociliary clearance, reduction in minute volume, and changes in glutathione levels and glutathione-mediated ADH3 activity.

Functional changes in the respiratory epithelium could have significant effects on the subsequent uptake of inhaled formaldehyde. Squamous metaplasia, a tissue conversion that is an adaptive response that occurs in nasal epithelium exposed to toxic levels of formaldehyde, has been observed in rats exposed to ≥2.46 mg/m^3^ formaldehyde for longer than 18 months. This type of dynamic tissue remodeling of nasal airways can affect formaldehyde dosimetry, as squamous metaplastic tissue is known to absorb considerably less formaldehyde than other epithelial types (Kamata et al., 1997). This is of critical concern for dosimetric modeling efforts, which typically rely on results from simulations of acute, rather than prolonged, exposure. The highest flux levels of formaldehyde in simulations of the rat nose in (Kimbell et al., 2001b) are estimated to be in the region just posterior to the nasal vestibule. A consequence of squamous metaplasia is a “push” of the higher levels of formaldehyde flux toward the more distal regions of the nose (Kimbell et al., 1997b). Uncertainties in the modeling of formaldehyde dosimetry are presented in (Subramaniam et al., 2008) and are discussed in Appendix C.1.12. A similar concern is raised regarding the observation that exposure affects the integrity and/or function of the mucociliary layer, as discussed previously and further evaluated in Appendix C.7.

Exposure-induced changes to factors involved in the detoxification of formaldehyde could also affect its toxicokinetics during a subsequent challenge. The enzyme ADH3 is central to the metabolism of formaldehyde; however, exposure to formaldehyde in turn alters the activity of ADH3-dependent critical metabolic pathways. For example, transcription of ADH3 correlates with the proliferative states in human oral keratinocytes (Nilsson et al., 2004; Hedberg et al., 2000). In rodent lung, an increase in ADH3 activity affects other ADH3 substrates involved in protein modification and cell signaling (Que et al., 2005). Other pathways of ADH3 include oxidation of retinol and long-chain primary alcohols and reduction of S-nitrosoglutathione (GSNO). GSNO can accelerate ADH3-mediated formaldehyde oxidation and, likewise, formaldehyde increases ADH3-mediated GSNO reduction nearly 25-fold. Because GSNO is an endogenous bronchodilator and reservoir of nitric oxide (NO) activity, ADH3-mediated reduction of GSNO can cause a deregulation of NO (Reviewed in (Thompson et al., 2010)).

Similarly, GSH is essential to detoxification of formaldehyde through the major pathway. GSH is present in most cells at levels far in excess of formaldehyde. In humans, the HMGSH levels are high since circulating GSH concentrations are ≈50 times higher than formaldehyde (Sanghani et al., 2000). It is estimated that ≈50–80% of formaldehyde in animal cells is reversibly bound to GSH (Uotila and Koivusalo, 1989) and to a minor extent bound reversibly to tetrahydrofolate (Heck et al., 1982). Inhaled formaldehyde is similarly expected to undergo detoxification following reversible binding to GSH. GSH levels are unchanged in tissue homogenates following acute exposures but represent a possible adaptive response that may be location-specific and changed with prolonged exposure. For example, repeated exposure to formaldehyde (18.45 mg/m^3^, 6 hours/day for 9 days) did not affect either the GSH levels or the specific activities of ADH3 and ALDH2 in the nasal mucosa F344 rats (Casanova-Schmitz et al., 1984a). Interfacial DNA levels can be increased by glutathione depletion. This was tested by Casanova and Heck (Casanova and Heck, 1987) by exposing rats for 3 hours on two consecutive days to a range (1.11–12.3 mg/m^3^) of formaldehyde by inhalation, on Day 1 to nonlabeled formaldehyde and on Day 2 to a mixture of [^3^H] and [^14^C]-labeled formaldehyde. Two hours before the exposure on the second day, the animals were injected i.p. with 300 mg/kg phorone, a GSH depleting agent. The authors reported a 90–95% decrease in GSH levels and a significant decrease in metabolic incorporation in nasal respiratory and olfactory mucosa and bone marrow of phorone-treated rats. In contrast, the ^3^H/^14^C ratios of IF DNA were increased in a concentration-dependent manner for both phorone-treated and control groups of rats, albeit the levels were slightly higher in phorone-treated rats compared to control rats. Thus, depletion of GSH appeared to result in more unmetabolized formaldehyde available for covalent binding (crosslink formation) following 3-hour exposure.

#### Summary of potential modifying factors

The toxicokinetics of formaldehyde may be influenced by certain formaldehyde-related effects, such as mucociliary clearance (Morgan et al., 1983), reflex bradypnea (rodents only) and reduction in minute volume (Chang et al., 1981; Chang et al., 1983), and dynamic tissue remodeling (Kamata et al., 1997), which have the potential to modulate formaldehyde uptake and clearance. For example, during repeated inhalation exposure to formaldehyde, mice but not rats lower their minute volume thereby restricting the intake of the gas (Chang et al., 1981; Chang et al., 1983), which may impact dosimetric adjustment if extrapolated to humans. Exposure to formaldehyde can also cause a perturbation of ADH3-dependent pathways involved in cell proliferation (Nilsson et al., 2004; Hedberg et al., 2000), protein modification and cell signaling (Que et al., 2005), GSNO metabolism, and deregulation of nitric oxide-dependent pathways (Thompson et al., 2010). In rats exposed by inhalation to formaldehyde, a rapid GSH depletion can result in more free formaldehyde available for covalent binding and lowering metabolic incorporation (Casanova and Heck, 1987).

#### Specific uncertainties regarding the potential impact of endogenous formaldehyde

Since formaldehyde is produced through normal cellular metabolism, several uncertainties exist which might impact the metabolism of exogenous formaldehyde in the body. This section covers the sources of endogenous formaldehyde, comparisons about its concentration gradient, its metabolism and reactivity, and the impact of inhaled formaldehyde on endogenous formaldehyde.

##### Sources of endogenous formaldehyde

Formaldehyde is endogenously produced through normal cellular metabolism from three main sources. As detailed below and outlined in Figure C-5, these sources include: (1) enzymatic reactions, (2) nonenzymatic reactions, and (3) as a metabolic byproduct of cellular metabolism of xenobiotics (e.g., drugs, environmental contaminants) that enter the body.

(1) Enzymatic pathways that generate formaldehyde endogenously as a normal component of cellular metabolism include four metabolic pathways: methylamine deamination, choline oxidation, histone lysine demethylation, and amino acid metabolism (serine, glycine, methionine). Formaldehyde can also be generated through endogenous generation from exogenous sources (e.g., methanol). These enzymatic sources are summarized in Figure C-5.

Methylamine is endogenously produced through amine catabolism, which upon deamination carried out by the enzyme semicarbazide-sensitive amino oxidase (SSAO) gives rise to formaldehyde. Choline oxidation is another endogenous metabolic process by which formaldehyde is generated. Choline is converted to glycine through several intermediary steps (choline à betaine à dimethylglycine (DMG) à sarcosine à glycine. The last two steps in this pathway are catalyzed by dimethylglycine dehydrogenase (DMGDH) and sarcosine dehydrogenase (SDH), respectively, using flavin adenine dinucleotide (FAD) as a cofactor. During these two steps the dehydrogenases nonenzymatically condense tetrahydrofolate (THF) with formaldehyde generating 5, 10-methylene-THF (5, 10-CH2-THF), also known as “active formaldehyde.”

The other mechanism of endogenous formaldehyde production is through histone lysine demethylation, which is carried out by two classes of enzymes near the nucleus in a cell. One is a FAD-dependent amine oxidase, also known as lysine-specific demethylase 1 (LSD1/KDM1). The other one belongs to the Jumonji C terminal (JmjC) domain-containing histone demethylase (JHDM1/KDM2A). The LSD1 and JHDM1 enzymes act, respectively, on dimethyl lysine and trimethyl lysine converting them to monomethyl- and dimethyl lysine with the liberation of formaldehyde as an intermediary product (Shi et al., 2004). Formaldehyde can also be generated from methanol by either enzymatic or nonenzymatic pathways.

(2) Formaldehyde can also be formed nonenzymatically by the spontaneous reaction of methanol with hydroxyl radicals, wherein intracellular hydrogen peroxide is converted to the hydroxyl radical through the Fenton reaction (Cederbaum and Qureshi, 1982). Another mechanism of nonenzymatic production of formaldehyde is through lipid peroxidation of polyunsaturated fatty acids (PUFA) (Slater, 1984; Shibamoto, 2006). It is known that a certain level of oxidative stress and lipid peroxidation occurs in every individual, and these oxidative processes are likely to contribute to endogenous formaldehyde production (Zararsiz et al., 2006; Ozen et al., 2008).

(3) Formaldehyde may also be produced intracellularly during microsomal cytochrome P450 enzyme-catalyzed oxidative demethylation of N-, O-, and S-methyl groups of xenobiotics (ATSDR, 2008) that enter the body through dietary, environmental, or medicinal exposures, as shown in Figure C-5. Dhareshwar and Stella (2008) estimated that formaldehyde released from prodrugs is ≈2–100 mg. However, the authors point out that in humans with endogenous blood levels of ≈2–3 μg/g of blood total formaldehyde (Heck et al., 1985), the fraction of formaldehyde released from xenobiotics may contribute a small fraction to the endogenous pool (Dhareshwar and Stella, 2008).

Figure C-5 Endogenous and dietary sources of formaldehyde production

Formaldehyde is generated in the body through (a) Enzymatic mechanisms - involving (i) Steroid biosynthesis – from lanosterol, (ii) Intermediary metabolism – from methylamine (Yu and Zuo, 1996), (iii) Choline metabolism (Binzak et al., 2000), (iv) Stress – through adrenaline (Yu et al., 1997), (v) histone lysine demethylation (Shi et al., 2004) and (vi) Methanol metabolism (enzymatic) (Skrzydlewska, 2003); (b) Nonenzymatic mechanisms – (i) Methanol oxidation (Cederbaum and Qureshi, 1982) (ii) Lipid Peroxidation of polyunsaturated fatty acids or PUFA (Shibamoto, 2006) and (iii) Oxidative Stress (Slater, 1984); (c) Xenobiotic metabolism – demethylation of chemicals (ATSDR, 2008) and prodrugs (Dhareshwar and Stella, 2008).

[underlined: Abbreviations]: DMG: dimethyl glycine; C1: one carbon; NNK: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone; THF: tetrahydrofolate; LSD1/KDM1, lysine (K)-specific demthylase 1; JHDM1/KDM2A, JumonjiC-domain containing histone demthylase 1.

[underlined: Enzymes]: a, alcohol dehydrogenase-1 (ADH1) in primates and ADH1 and catalase in rodents; b, semicarbazole-sensitive amine oxidase; c, serine hydroxymethyl transferase; d, sarcosine dehydrogenase; e, dimethylglycine dehydrogenase.

The presence of comparatively high levels of endogenous formaldehyde in cells of the URT presents an important uncertainty to evaluating the toxicokinetics of inhaled formaldehyde. Once inhaled formaldehyde interacts with aqueous matrices such as mucus and is hydrated, the biochemical interactions of inhaled formaldehyde and endogenous formaldehyde are assumed to be very similar, given that there are no differences in chemical structure. However, other than in the nucleus (i.e., the experiments detailing DNA adducts), no data are available to inform where and to what extent endogenous and exogenous formaldehyde may be available to participate in these reactions.

Although much is unknown regarding the impact of endogenous formaldehyde on inhaled formaldehyde uptake and metabolism as outlined in the sections above, uncertainties relevant to interpreting the potential for biological differences between inhaled formaldehyde and endogenous formaldehyde are important to specify. Several of these uncertainties, which are essential to consider when comparing the distribution and macromolecular binding of endogenous formaldehyde versus inhaled formaldehyde, are outlined below.

##### Potential heterogeneity due to concentration gradients and interindividual differences

Endogenous formaldehyde is known to be produced within all cells of the URT. The specific levels of endogenous formaldehyde within each type of cell, or even within the various components of the nasal tissue (e.g., the respiratory mucosa lining the maxilloturbinates; the squamous epithelium lining the luminal surface of the nasal vestibule), have not been experimentally defined and are likely to vary across individuals.

In contrast to endogenous formaldehyde, which is likely homogenously distributed within a tissue type, decreasing concentrations of inhaled exogenous formaldehyde reach deeper into the nasal mucosa. (Georgieva et al., 2003) modeled the penetration of inhaled formaldehyde across nasal tissue in the rat using a distributed parameter model; their results predict a sharp concentration gradient vertically across the tissue down to the basement membrane where the concentration levels off at steady state at a thickness of 11 m from the mucus layer. Therefore, interactions of the exogenous formaldehyde are more enriched in the epithelial cells and associated cellular/extracellular components along the apical surface of the respiratory mucosa. These differences in distribution can complicate comparisons of the relative contributions of exogenous and endogenous formaldehyde to macromolecular binding. Thus, measured differences in these levels from tissue isolates do not necessarily reflect the comparative levels in the target cells. However, it would be methodologically arduous to isolate select portion(s) of the respiratory mucosa for comparison, and as such, it does not appear that any studies have done so.

##### Possible differences in metabolism and reactivity of endogenous formaldehyde

As compared to exogenous formaldehyde, for which it is unknown how quickly it may be detoxified by the normal cellular machinery, the production and subsequent detoxification of endogenous formaldehyde appears to be kept under strict control. As mentioned earlier, the majority of endogenous formaldehyde is reversibly bound to GSH at any time (Sanghani et al., 2000).

The regulation of endogenous formaldehyde appears to be imperfect, given the presence of endogenous N^2^-HOCH_2_-dG (dG) adducts (Swenberg et al., 2011). The endogenous adduct levels reported by (Swenberg et al., 2011) are about the same as the exogenous dG adduct levels resulting from a single 6-hour exposure to ≈10 ppm formaldehyde. (Given that endogenous formaldehyde is present continuously, the equivalent continuous exposure to exogenous formaldehyde that would result in the same dG levels must be somewhat less than 10 ppm.) Some insight into the implications of this observation is obtained by comparing the endogenous levels reported by (Heck et al., 1982) with results from the toxicokinetic modeling of exogenous formaldehyde levels in the rat nasal tissue. (Georgieva et al., 2003) modeled the penetration of inhaled formaldehyde across nasal tissue using a distributed parameter model that was calibrated with data on DPX levels induced by exposure to formaldehyde and which used the DNA-binding constant determined in vitro by Heck and Keller (Heck and Keller, 1988). These authors predicted an exogenous level in nasal tissue of around 17 µM from a 6-ppm exposure. This value is roughly 25 times lower than the total endogenous level of 12.6 µg/g or 420 µM reported by (Heck et al., 1982) in rat nasal tissue. This large difference is at odds with the above observation of similar dG adduct levels for endogenous and exogenous formaldehyde in the (Swenberg et al., 2011) experiment. The apparent discordance may suggest that much, but not all, of the endogenous formaldehyde (measured by (Heck et al., 1982)) must be bound or sequestered in a way that reduces its ability to react with DNA, in comparison with exogenous formaldehyde.

##### Impact of inhaled formaldehyde on the function of endogenous formaldehyde

Although formaldehyde inhalation does not appear to result in a measurable change in the total level of formaldehyde in the nasal tissue of rats (Heck et al., 1982), it has yet to be determined whether exposure results in any changes to the normal functions of endogenous formaldehyde. For example, in the study by (Lu et al., 2011), rats exposed to ^13^C-formaldehyde showed a concentration-dependent increase in the exogenous hm-dG adduct levels, and the corresponding endogenous N^2^-hm-dG adduct levels were highly variable at different exposure concentrations in the nasal tissues. In addition to the potential “compartmentalization” differences mentioned above, the endogenous DNA adduct levels, reflective of endogenous formaldehyde, do not appear to be static. Possible effects of exogenous formaldehyde exposure on metabolism and distribution processes of endogenous formaldehyde cannot be conclusively ruled out. However, no appreciable changes in the number of adducts formed as a result of interactions of endogenous formaldehyde with cellular constituents have been noted, even in the presence of formaldehyde exposure (Yu et al., 2015b).

### C.1.5 Conclusions Regarding the Toxicokinetics of Inhaled Formaldehyde Within the POE

Within the POE, a majority of inhaled formaldehyde is rapidly retained in the URT of humans and experimental animals, irrespective of species differences in the anatomy, physiology, and breathing patterns. Following inhalation, formaldehyde levels are successively reduced as formaldehyde from the air penetrates through the various components of the nasal mucosa. Formaldehyde levels are reduced through interactions with components of the mucus and through mucociliary clearance; through reactions with cellular materials at the plasma membrane of the respiratory epithelium; via interactions with GSH and other macromolecules in the intracellular and extracellular space; through localized metabolism and conjugation reactions; and through reversible interactions with intracellular materials. This results in the formation of a gradient of formaldehyde across the tissue space, with the greatest formaldehyde concentration at the apical surface of the mucosa, and the lowest levels of formaldehyde at deeper components of the tissue, such as the nasal associated lymphoid tissues (NALT) and blood vessels. In the URT, formaldehyde is metabolized by cytosolic ADH3 (major) and mitochondrial ALDH2 (minor) enzymes to formate which is further metabolized to CO_2_ and eliminated in expired air, enters the 1C pool leading to metabolic incorporation, or is excreted in urine unchanged.

### C.1.6 Toxicokinetics of inhaled formaldehyde beyond the portal of entry

Consistent with the previously described concentration gradient of inhaled formaldehyde within the POE, multiple studies report that very little inhaled formaldehyde reaches the vasculature of the respiratory tract to allow for absorption into the systemic circulation. Similarly, there is very little evidence that inhaled formaldehyde is distributed to tissues such as the bone marrow, liver, or brain. Studies examining the potential for direct interactions of inhaled formaldehyde with cellular macromolecules at distal sites have also not reported any evidence of these effects, despite observing that endogenous formaldehyde elicits such effects. Although the evidence is not entirely conclusive, and some uncertainties remain to be explored, the currently available data support an overall conclusion that appreciable amounts of inhaled formaldehyde are not distributed outside of the URT.

### C.1.7 Levels of Endogenous and Inhaled Formaldehyde in Blood and Distal Tissues

Using the detection methods employed by (Heck et al., 1982), two studies from the same group reported endogenous levels of total formaldehyde in blood to be 2.61 ± 0.14 μg/g of blood in unexposed human subjects (Heck et al., 1985), 2.24 ± 0.07 and 2.71± 0.29 μg/g of blood in control F344 (Heck et al., 1985) and SD rats (Kleinnijenhuis et al., 2013), respectively, and 2.42 ± 0.09 μg/g of blood in unexposed rhesus monkeys (Casanova et al., 1988), providing relatively consistent measurements across species with an average blood level of ≈2.5 μg/g (≈0.1 mM) (see Table C-7). Levels of endogenous formaldehyde higher than in blood were also detected in other distal tissues of rats, although the nasal tissue contained the highest levels (Heck et al., 1982). The blood formaldehyde levels were not significantly changed when tested during exposure or shortly after exposure to formaldehyde concentrations ranging from 2.3 to 7.4 mg/m^3^ across the three species, with varying durations of exposure (Heck et al., 1985; Casanova et al., 1988). The lack of increase in blood formaldehyde levels could also be due to the metabolism of formaldehyde in human erythrocytes, which are known to contain the formaldehyde metabolizing enzymes ADH3 (Uotila and Koivusalo, 1987) and ALDH2 (Inoue et al., 1979).

The tissue levels of endogenous formaldehyde determined experimentally by (Heck et al., 1982) may be highly uncertain. (Campbell Jr et al., 2020) assessed these values to be 20× lower based upon their modeling estimates and attributed this discrepancy to the potential for the Heck et al. measurement methodology to overestimate tissue formaldehyde levels. This is addressed again in Appendix C.1.12 in a discussion of model-derived estimates of the effects of endogenous formaldehyde on inhaled formaldehyde dosimetry.

EPA notes that while these data indicate that inhaled formaldehyde is not absorbed into the systemic circulation, a rough bounding calculation based on the human data indicates that the (Heck et al., 1985) experiment lacks the sensitivity needed to reach this conclusion. This bounding calculation assumes that the 2.3 mg/m^3^ of inhaled formaldehyde completely mixes with the blood, and because of its high solubility, it has a volume of distribution equal to that of all body water [0.57 L/kg of body weight; (Guyton, 1991)]. Using these parameters, the Heck et al. (1985) experiment is estimated to result in an increased blood formaldehyde concentration of 0.016 μg/g^4^. This quantity is one-half the experimental error of 0.03 μg/mL. Hence, even if all of the 2.3 mg/m^3^ of inhaled formaldehyde completely mixes with the blood, under the experimental protocol above for human exposure, formaldehyde blood concentration would increase by 0.016 μg/g, a quantity that cannot be detected by the (Heck et al., 1985) experiment.^5^ Moreover, this quantity is two orders of magnitude lower than the endogenous blood levels. Hence, these results are consistent with a lack of ^14^C radiolabel increases in the plasma of rats exposed to ^14^C formaldehyde (Heck et al., 1983), as well as a lack of increase in total formaldehyde calculated following exposure of rats to ^13^C formaldehyde (Kleinnijenhuis et al., 2013). Altogether, the data argue that the amount of inhaled formaldehyde absorbed into the blood is not likely to be significant, even if one assumes that only 5% of the endogenous formaldehyde in blood is not sequestered.

A similar trend was observed in distal tissues. Heck et al. (1983) exposed rats to a range of ^14^C-formaldehyde concentrations (6.14–29.48 mg/m^3^ for 6 hours) and observed that the ratio of tissue distribution relative to plasma radioactivity (μmole equivalents/g tissue) was not correlated with the exposure concentration, except in the esophagus (Heck et al., 1983). Mucociliary transport from the nose and trachea may have led to these relatively higher esophageal levels. Overall, these data also indicate that tissue distribution of formaldehyde levels were independent of the exposure concentration and duration of exposure.

Overall, the published data demonstrate no significant increase in formaldehyde levels in blood following formaldehyde inhalation. These data also report no significant differences in tissue and blood formaldehyde levels between preexposed and naïve animals. Such observations were obtained from short-term experimental animal studies based on ^14^C-radiolabeling by GC-MS. The use of only this approach is problematic because there is no distinction as to whether the formaldehyde measured in these studies is free, reversibly or irreversibly bound, measured as formate, or part of the one-carbon pool. Nevertheless, taken together with the bounding calculations and relative activity calculations described above, the lack of significance of exogenous formaldehyde reaching distal tissues appears to hold even given the uncertainty.

Table C-7 Summary of blood and tissue levels of total^a^ formaldehyde in humans and experimental animals following inhalation exposure to formaldehyde

Reference and species | Exposure and analysis | | Observations
Heck et al. (1985); Human volunteers; Male, n = 4; female, n = 2; 24–44 years old | 2.34 ± 0.07 mg/m^3^ CH_2_O ([underlined: source not specified]); 40 min exposure in a walk-in chamber; venous blood collected before and after exposure; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | Total^a^ formaldehyde (μg/g of blood)
Heck et al. (1985); Human volunteers; Male, n = 4; female, n = 2; 24–44 years old | | | Before exposure: | | 2.61 ± 0.14
Heck et al. (1985); Human volunteers; Male, n = 4; female, n = 2; 24–44 years old | | | After exposure: | | 2.77 ± 0.28
Casanova et al. (1988); Monkeys, rhesus; Male, n = 4;; 200–250 g | 7.37 mg/m^3^ CH_2_O (from PFA); 6 hrs/d, 4 d/wk, 4 wks; chamber inhalation; whole-body exposure; pre- and postexposure blood collected; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | Total^a^ formaldehyde (μg/g of blood)
Casanova et al. (1988); Monkeys, rhesus; Male, n = 4;; 200–250 g | 7.37 mg/m^3^ CH_2_O (from PFA); 6 hrs/d, 4 d/wk, 4 wks; chamber inhalation; whole-body exposure; pre- and postexposure blood collected; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | Before exposure: | | 2.42 ± 0.09
Casanova et al. (1988); Monkeys, rhesus; Male, n = 4;; 200–250 g | 7.37 mg/m^3^ CH_2_O (from PFA); 6 hrs/d, 4 d/wk, 4 wks; chamber inhalation; whole-body exposure; pre- and postexposure blood collected; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | 0 min. after exposure | | 1.84 ± 0.15
Casanova et al. (1988); Monkeys, rhesus; Male, n = 4;; 200–250 g | 7.37 mg/m^3^ CH_2_O (from PFA); 6 hrs/d, 4 d/wk, 4 wks; chamber inhalation; whole-body exposure; pre- and postexposure blood collected; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | 40 min. after exposure: | | 2.04 ± 0.40
Heck et al. (1985); Rats, Fischer; Male, n=4, Mean±SE = 232 ± 22 g | 17.69 ± 2.95 mg/m^3^ CH_2_O ([underlined: source not specified]); 2-hrs exposure; chamber inhalation; nose-only; controls–no exposure; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | Total^a^ formaldehyde (μg/g of blood
Heck et al. (1985); Rats, Fischer; Male, n=4, Mean±SE = 232 ± 22 g | 17.69 ± 2.95 mg/m^3^ CH_2_O ([underlined: source not specified]); 2-hrs exposure; chamber inhalation; nose-only; controls–no exposure; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | Before exposure: | | 2.24 ± 0.07
Heck et al. (1985); Rats, Fischer; Male, n=4, Mean±SE = 232 ± 22 g | 17.69 ± 2.95 mg/m^3^ CH_2_O ([underlined: source not specified]); 2-hrs exposure; chamber inhalation; nose-only; controls–no exposure; Total CH_2_O measured as PFPH derivative by GC-MS/SIM | | After exposure: | | 2.50 ± 0.07
Kleinnijenhuis et al. (2013); Rats, Sprague Dawley; Male, n = 10; 12 wks-old | 12.3 mg/m^3^ ^13^CH_2_O (19.3% in aqueous solution: [underlined: source not specified]); 6-hrs exposure, Nose-only chamber; Blood samples collected before, during and after exposure; analyzed by HPLC-MS/MS after derivatizing with 2,4-DNPH | | Total^a^ formaldehyde (mg/L of blood^b^)
Kleinnijenhuis et al. (2013); Rats, Sprague Dawley; Male, n = 10; 12 wks-old | | | Before Exposure: | | 2.71 ± 0.29
Kleinnijenhuis et al. (2013); Rats, Sprague Dawley; Male, n = 10; 12 wks-old | | | During Exposure (3 hrs): | | 2.63 ± 1.12
Kleinnijenhuis et al. (2013); Rats, Sprague Dawley; Male, n = 10; 12 wks-old | | | During Exposure (6 hrs): | | 2.01 ± 0.48
Kleinnijenhuis et al. (2013); Rats, Sprague Dawley; Male, n = 10; 12 wks-old | | | After Exposure (^≈^6.2 hrs): | | 2.11 ± 0.35
Kleinnijenhuis et al. (2013); Rats, Sprague Dawley; Male, n = 10; 12 wks-old | | | After Exposure (6.5 hrs): | | 1.81 ± 0.22
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Rat tissue levels (mean ± SE) of total^a^ CH_2_O
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Tissue | Unexposed | Exposed
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Tissue | μg/g | μg/g
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Nasal mucosa | 12.6 ± 2.7 | 11.7 ± 3.6
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Liver | 6.03 ± 0.5 | NR
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Testes | 8.40 ± 3.0 | NR
Heck et al. (1982); Rats, Fischer; Male, n = 8; 200–250 g | 7.37 mg/m^3^ ^13^CH_2_O from PFA; 6 hrs/d; 10-d exposure; chamber inhalation; CH_2_O measured as PFPH derivative by GC/MS | | Brain | 2.91 ± 0.42 | NR
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | [underlined: Two groups]: (a) preexposure; (b) naïve; On Days 1–9: [underlined: group a)] received 18.42 mg/m^3^; CH_2_O (from PFA); whole body exposure, 6 hrs/d; [underlined: group b)]: no exposure. On day 10: groups a and b received ^14^C-CH_2_O (from PFA) for 6 hrs, nose-only exposure. Tissue homogenates counted with LSC for ^14^CO_2_ trapped in ethanolamine in 2-methoxy-ethanol counted for radioactivity | | Animals Exposed | Equivalents of ^14^C in tissues (Mean ± SE)
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | | | Nasal mucosa | Plasma
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | | naïve rats | 2,148 ± 255 | 76 ± 11
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | | preexposed | 2,251 ± 306 | 79 ± 7
Heck et al. (1983); Rats, Fischer; Male, n = 3;; 180–250 g | | | | Not significant | Not significant
Heck et al. (1983); Rats, Fischer,; Male, n = 12 | Naïve rats: dosed with 6.14, 12.28, 18.42 or 29.48 mg/m^3^ ^14^C-CH_2_O (from PFA); 6-hrs nose-only; sacrificed immediately after exposure; tissue homogenates counted with LSC. | Tissue | (DPM/g tissue)/(DPM/g plasma)^c^ | Tissue | (DPM/g tissue)/(DPM/g plasma)^c^
Heck et al. (1983); Rats, Fischer,; Male, n = 12 | Naïve rats: dosed with 6.14, 12.28, 18.42 or 29.48 mg/m^3^ ^14^C-CH_2_O (from PFA); 6-hrs nose-only; sacrificed immediately after exposure; tissue homogenates counted with LSC. | Esophagus | 4.94 ± 1.23 | Spleen | 1.59 ± 0.50
Heck et al. (1983); Rats, Fischer,; Male, n = 12 | Naïve rats: dosed with 6.14, 12.28, 18.42 or 29.48 mg/m^3^ ^14^C-CH_2_O (from PFA); 6-hrs nose-only; sacrificed immediately after exposure; tissue homogenates counted with LSC. | Kidney | 3.12 ± 0.47 | Heart | 1.09 ± 0.09
Heck et al. (1983); Rats, Fischer,; Male, n = 12 | Naïve rats: dosed with 6.14, 12.28, 18.42 or 29.48 mg/m^3^ ^14^C-CH_2_O (from PFA); 6-hrs nose-only; sacrificed immediately after exposure; tissue homogenates counted with LSC. | Liver | 2.77 ± 0.25 | Brain | 0.37 ± 0.06
Heck et al. (1983); Rats, Fischer,; Male, n = 12 | Naïve rats: dosed with 6.14, 12.28, 18.42 or 29.48 mg/m^3^ ^14^C-CH_2_O (from PFA); 6-hrs nose-only; sacrificed immediately after exposure; tissue homogenates counted with LSC. | Intestine | 2.64 ± 0.48 | Testes | 0.31 ± 0.05
Heck et al. (1983); Rats, Fischer,; Male, n = 12 | Naïve rats: dosed with 6.14, 12.28, 18.42 or 29.48 mg/m^3^ ^14^C-CH_2_O (from PFA); 6-hrs nose-only; sacrificed immediately after exposure; tissue homogenates counted with LSC. | Lung | 2.05 ± 0.36 | RBC | 0.30 ± 0.08

CH_2_O, formaldehyde; GC, gas chromatography; LC, liquid chromatography; MS, mass spectrometry; HPLC-MS/MS, high performance liquid chromatography/tandem mass spectroscopy; PFA, paraformaldehyde; SIM, selected ion monitoring; DNPH, dinitrophenyl hydrazine; PFPH, pentafluorophenyl hydrazine; DPM, disintegrations per minute; ND, not detected; UPLC, ultraperformance liquid chromatography; NaCNBH_3_, sodium cyanogen borohydride.

a Includes free and reversibly bound formaldehyde (Heck et al., 1982).

b Calculated concentration in blood and corrected for stability.

c Values (Mean ± SD) are ratios of concentrations (radioactivity) in tissues relative to plasma immediately after a 6-hour exposure to ^14^C-formaldehyde averaged for four concentration groups (n = 12/concentration).

#### Covalent binding of formaldehyde to macromolecules beyond POE

Formaldehyde has been shown to interact with macromolecules in blood or blood cells, but not in other distal organs as described below.

##### Evidence of covalent binding of formaldehyde to blood proteins

Formaldehyde has also been shown to covalently bind to serum proteins such as the amino acid valine in hemoglobin (Hb) forming N-methylvaline adducts in workers in plywood and laminate factory workers with occupational exposure (Bono et al., 2006). Also, with human serum albumin (HSA) it forms formaldehyde-HSA complexes (Thrasher et al., 1990). However, N^6^-formyllysine, another formaldehyde-induced protein adduct that also occurs endogenously, was not detectable in blood cells or in distal tissues (liver, lung, and bone marrow) in rats exposed to exogenous ^13^C-labeled formaldehyde (Edrissi et al., 2013a).

##### Evidence of DPX in the blood cells of formaldehyde exposed workers

DPXs have also been reported in the peripheral blood lymphocytes (PBLs) of formaldehyde-exposed workers (Shaham et al., 1996; Shaham et al., 1997; Shaham et al., 2003). Shaham et al. (1996) observed a statistically significant increase in DPX levels in PBLs compared to unexposed subjects and reported a linear relationship between years of exposure and the amount of DPX.

##### Lack of experimental evidence of endogenous and exogenous DNA monoadducts and DNA-protein crosslinks in blood and distal tissues

According to the available adduct studies, inhaled formaldehyde does not reach systemic tissues in concentrations sufficient to elicit detectable interactions of formaldehyde with DNA. In the bone marrow of monkeys (Moeller et al., 2011), and in the bone marrow, liver, lung, spleen, thymus, and blood of rats (Lu et al., 2010a), DNA monoadducts were formed by interactions with endogenous formaldehyde, but adducts formed from exogenous formaldehyde were not found (see Table C-8). It is important to note that (Moeller et al., 2011) observed 6–8 times higher endogenous N^2^-hm-dG adducts in the bone marrow compared to the nasal tissues of monkeys. Although there were some limitations with the experimental methods, including a possible overestimation of endogenous adducts due to reasons discussed (see Section C.1.3), the data support a general lack of systemic distribution of inhaled formaldehyde.

As described for the POE tissues, efforts have been made to differentiate covalent binding from metabolic incorporation in bone marrow. Male F344 rats were exposed to a mixture of ^3^H- and ^14^C-labeled formaldehyde for 6 hours at 0.37–18.42 mg/m^3^ 1 day after exposure to nonradioactive formaldehyde with the same exposure range (Casanova-Schmitz et al., 1984b). The authors extracted IF DNA from bone marrow (femur) and determined the ^3^H/^14^C ratios of different phases of DNA (i.e., AQ DNA and IF DNA). As previously described, a sample that contains adducts and crosslinks should have a higher ratio than a sample that primarily contains metabolically incorporated formaldehyde. In contrast to results in respiratory mucosa, bone marrow from the distal femur did not show an increased ^3^H/^14^C ratio in the IF DNA, AQ DNA, or proteins phase as a function of formaldehyde concentration (see Figure C-6). Therefore, the authors concluded that radiolabeled metabolites of formaldehyde reached the distal site (femur bone marrow) and were subsequently metabolically incorporated into macromolecules. In total, these data suggest that the labeling of bone marrow macromolecules was likely due to metabolic incorporation rather than due to covalent binding (Casanova-Schmitz et al., 1984b).

Recently Lai et al. (2016) developed an ultrasensitive mass spectrometry method which distinguishes unlabeled DPX from ^13^CD_2_-labeled DPX induced respectively, from endogenous and exogenous formaldehyde. The authors demonstrated that inhalation exposure of stable isotope labeled (^13^CD_2_) formaldehyde to rats (18.45 mg/m^3^; 6 hours/day; 1–4 days) and monkeys (2.5 mg/m^3^; 6 hours/day; 2 days) induced exogenous DPX in POE tissues such as nasal passages in both species, but not in distal tissues, such as bone marrow and peripheral blood monocytes (rats and monkeys) and liver (monkeys), although endogenous DPX were detectable in all tissues (see Table C-9). These observations further confirm the lack of experimental evidence of formaldehyde distribution to distal tissues.

Figure C-6 ^3^H/^14^C ratios in macromolecular extracts from rat bone marrow following 6-hour exposure to ^14^C- and ^3^H-labeled formaldehyde (0.3, 2, 6, 10, and 15 ppm, corresponding to 0.37, 2.46, 7.38, 12.3, 18.42 mg/m^3^, respectively)

Source: Adapted from Casanovaschmitz et al. (1984).

Table C-8 Summary of endogenous and exogenous DNA monoadducts in distal tissues of monkeys and rats following inhalation exposure of ^13^CD_2_-labeled formaldehyde

Reference and design | Exposure and analysis^a^ | | | CH_2_O conc. | Observations
Moeller et al. (2011); Monkeys, cynomolgus; n = 3 | 2.3 and 7.5 mg/m^3^ [^13^CD_2_]-CH_2_O from PFA; 6 hrs/d; for 2 d; whole-body exposure; sacrificed immediately after exposure; necropsied within 3 hrs; nasal mucosa and bone marrow collected; tissue DNA extracted, reduced with NaCNBH_3_, digested, and analyzed by nano-UPLC/MS. | | | (mg/m^3^) | Bone marrow
Moeller et al. (2011); Monkeys, cynomolgus; n = 3 | | | | (mg/m^3^) | Endogenous adducts | Exogenous adducts
Moeller et al. (2011); Monkeys, cynomolgus; n = 3 | | | | | DNA adducts/10^7^dG
Moeller et al. (2011); Monkeys, cynomolgus; n = 3 | | | | 2.34 | 17.5 ± 2.6 | ND
Moeller et al. (2011); Monkeys, cynomolgus; n = 3 | | | | 7.5 | 12.4 ± 3.6 | ND
Yu et al. (2015b); Monkeys, cynomolgus; | 0 (air control), 2.4 or 7.5 mg/m^3^ [^13^CD_2_]-CH_2_O from [^13^CD_2_]PFA; nose-only exposure; 6 hrs/d for 2 consecutive d; Sacrificed immediately after exposure; Tissue DNA was extracted, reduced with NaCNBH_3_, digested, and analyzed by nano-UPLC-MS/MS | Distal tissue | | | N^2^-hm-dG/10^7^ dG
Yu et al. (2015b); Monkeys, cynomolgus; | | Air control | | 0 | 10.18 ± 1.35 | ND
Yu et al. (2015b); Monkeys, cynomolgus; | | Scrapped bone marrow | | 7.5 | 11.00 ± 2.01 | ND
Yu et al. (2015b); Monkeys, cynomolgus; | | Air control | | 0 | 5.65 ± 2.12 | ND
Yu et al. (2015b); Monkeys, cynomolgus; | | Saline extrusion bone marrow | | 7.5 | 4.41 ± 1.00 | ND
Yu et al. (2015b); Monkeys, cynomolgus; | | Air control | | 0 | 3.64 ± 1.09 | ND
Yu et al. (2015b); Monkeys, cynomolgus; | | White blood cells | | 7.5 | 3.79 ± 1.19 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | 12.3 mg/m^3^ [^13^CD_2_]-CH_2_O from [^13^CD_2_]PFA; 6 hrs/d, 1 or 5 d; nose-only exposure; Sacrificed immediately after exposure. Lung, liver, spleen, bone marrow, thymus, and blood collected; tissue DNA extracted, reduced with NaCNBH_3_, digested, and analyzed by nano-UPLC-MS/MS | Adduct | N^2^-hm-dG/10^7^ dG^a^
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Duration | 1 day | | 5 days
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Tissue | Endogenous | Exogenous | Endogenous | Exogenous
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Lung | 2.39 ± 0.16^b^ | ND^c^ | 2.61 ± 0.35 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Liver | 2.66 ± 0.53 | ND | 3.24 ± 0.42 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Spleen | 2.35 ± 0.31 | ND | 2.35 ± 0.59 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Bone marrow | 1.05 ± 0.14 | ND | 1.17 ± 0.35 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Thymus | 2.19 ± 0.36 | ND | 1.99 ± 0.30 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Blood^d^ | 1.28 ± 0.38 | ND | 1.10 ± 0.28 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Adduct | N^6^-hm-dA/10^7^ dA^a^
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Duration | 1 day | | 5 days
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Distal Tissue | Endogenous | Exogenous | Endogenous | Exogenous
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Lung | 2.62 ± 0.24 | ND | 2.47 ± 0.55 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Liver | 2.62 ± 0.46 | ND | 2.87 ± 0.65 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Spleen | 1.85 ± 0.19 | ND | 2.23 ± 0.89 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Bone marrow | 2.95 ± 1.32 | ND | 2.99 ± 0.08 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Thymus | 2.98 ± 1.11 | ND | 2.48 ± 0.11 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Blood^d^ | 3.80 ± 0.29 | ND | 3.66 ± 0.78 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Adduct | dG-CH_2_-dG/10^7^ dG^a^
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Duration | 1 day | | 5 days
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Distal Tissue | Endogenous | Exogenous | Endogenous | Exogenous
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Lung | 0.20 ± 0.04^e^ | ND | 0.20 ± 0.03 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Liver | 0.18 ± 0.05 | ND | 0.21 ± 0.08 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Spleen | 0.15 ± 0.06 | ND | 0.16 ± 0.08 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Bone marrow | 0.09 ± 0.01 | ND | 0.11 ± 0.03 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Thymus | 0.10 ± 0.03 | ND | 0.19 ± 0.03 | ND
Lu et al. (2010a); Rats, Fisher; Male, n = 5–8 | | Blood^d^ | 0.12 ± 0.09 | ND | 0.10 ± 0.07 | ND
Yu et al. (2015b); Rats, Fischer | 0 (air control), 2.4 or 7.5 mg/m^3^ [^13^CD_2_]-CH_2_O from [^13^CD_2_]PFA; nose-only exposure; 6 hrs/d for 2 consecutive d; Sacrificed immediately after exposure; tissues collected. Tissue DNA was extracted, reduced with NaCNBH_3_, digested, and analyzed by nano-UPLC-MS/MS | Formaldehyde exposure duration | Rat bone marrow | | Rat white blood cells
Yu et al. (2015b); Rats, Fischer | | Formaldehyde exposure duration | N^2^-OHMe-dG (adducts/10^7^ dG)
Yu et al. (2015b); Rats, Fischer | | Formaldehyde exposure duration | Endogenous^f^ | Exogenous | Endogenous^f^ | Exogenous
Yu et al. (2015b); Rats, Fischer | | Air control | 3.58 ± 0.99 | ND | 2.76 ± 0.66 | ND
Yu et al. (2015b); Rats, Fischer | | 7 d | 3.37 ± 1.56 | ND | 2.62 ± 1.12 | ND
Yu et al. (2015b); Rats, Fischer | | 14 d | 2.72 ± 1.36 | ND | 2.26 ± 0.46 | ND
Yu et al. (2015b); Rats, Fischer | | 21 d | 2.44 ± 0.96 | ND | 2.40 ± 0.47 | ND
Yu et al. (2015b); Rats, Fischer | | 28 d | 3.43 ± 2.20 | 0.34^g^ | 2.49 ± 0.50 | ND
Yu et al. (2015b); Rats, Fischer | | 28 d + 6 hrs PE | 2.41 ± 1.14 | ND | 2.97 ± 0.58 | ND
Yu et al. (2015b); Rats, Fischer | | 28 d + 24 hrs PE | 4.67 ± 1.84 | ND | 2.57 ± 0.58 | ND
Yu et al. (2015b); Rats, Fischer | | 28 d + 72 hrs PE | 5.55 ± 0.76 | ND | 1.75 ± 0.26 | ND
Yu et al. (2015b); Rats, Fischer | | 28 d + 168 hrs PE | 2.78 ± 1.94 | ND | 2.61 ± 1.22 | ND
Yu et al. (2015b); Rats, Fischer | | Distal tissue | N^2^-OHMe-dG (adducts/10^7^ dG)
Yu et al. (2015b); Rats, Fischer | | Distal tissue | Air control | | 28-day exposure
Yu et al. (2015b); Rats, Fischer | | Distal tissue | Endogenous | Exogenous | Endogenous | Exogenous
Yu et al. (2015b); Rats, Fischer | | Thymus | 0.78 ± 0.04 | ND | 0.63 ± 0.06 | ND
Yu et al. (2015b); Rats, Fischer | | TBLN | 3.46 ± 1.24 | ND | 3.01 ± 0.71 | ND
Yu et al. (2015b); Rats, Fischer | | Lymph nodes | 2.99 ± 0.85 | ND | 2.80 ± 1.38 | ND
Yu et al. (2015b); Rats, Fischer | | Trachea | 3.18 ± 0.72 | ND | 2.63 ± 0.92 | ND
Yu et al. (2015b); Rats, Fischer | | Lung | 2.29 ± 0.24 | ND | 2.13 ± 0.26 | ND
Yu et al. (2015b); Rats, Fischer | | Spleen | 2.18 ± 0.19 | ND | 1.83 ± 0.25 | ND
Yu et al. (2015b); Rats, Fischer | | Kidneys | 2.17 ± 0.60 | ND | 1.99 ± 0.09 | ND
Yu et al. (2015b); Rats, Fischer | | Liver | 1.97 ± 0.38 | ND | 1.80 ± 0.02 | ND
Yu et al. (2015b); Rats, Fischer | | Brain | 2.13 ± 0.17 | ND | 2.35 ± 1.00 | ND

Abbreviations: PFA, paraformaldehyde; UPLC, ultra-pressure liquid chromatography; MS, mass spectrometry; N2-hm-dG, N2-hydroxymethyl-deoxyguanosine; N6-hm-dG, N6-hydroxymethyl-deoxyadenosine; dG-CH2-dG, dG-dG crosslink; TBLN, tracheal bronchial lymph nodes; ND, not detected

a The limit of detection for dG monoadducts, dA monoadducts, and dG-dG crosslinks was ≈240, ≈75, and ≈60 atto mol, respectively.

b n = 4–5 tissues.

c Not detectable in 200 µg of DNA.

d 60–100 µg of DNA was typically used for analysis of white blood cells isolated from blood.

e n = 3.

f No statistically significant difference was found using the 2-sided Dunnett’s test (multiple comparisons with a control).

g The amount of exogenous N2-hm-dG adducts that was found in only 1 bone marrow sample analyzed by AB SCIEX Triple Quad 6500.

Table C-9 Summary of endogenous and exogenous DNA-protein crosslinks in distal tissues of monkeys and rats following inhalation exposure of ^13^CD_2_labeled formaldehyde

Reference and design | Exposure and analysis | Tissue or Cell Type | Exposure duration (days) | Formaldehyde (mg/m^3^) | Endogenous dG-Me-Cys (crosslink/ 10^8^ dG) | Exogenous dG-Me-Cys (crosslink/ 10^8^ dG)
Lai et al. (2016); Monkeys, cynomolgus; N = 4-5 in PBMC and Bone Marrow; N = 6 in liver | 0 (air control) or 7.4 mg/m^3^ [13CD2]-CH2O from PFA; 6 hrs/d; for 2 d; whole-body exposure; PBMC, bone marrow and liver collected; tissue DNA extracted; dG-Me-Cys purified on HPLC and analyzed by nano-LC/ESI/MS-MS. | PBMC | 2 | 0 | 1.34 ± 0.25 | ND
Lai et al. (2016); Monkeys, cynomolgus; N = 4-5 in PBMC and Bone Marrow; N = 6 in liver | | PBMC | 2 | 7.4 | 1.57 ± 0.58 | ND
Lai et al. (2016); Monkeys, cynomolgus; N = 4-5 in PBMC and Bone Marrow; N = 6 in liver | | Bone Marrow | 2 | 0 | 2.30 ± 0.30 | ND
Lai et al. (2016); Monkeys, cynomolgus; N = 4-5 in PBMC and Bone Marrow; N = 6 in liver | | Bone Marrow | 2 | 7.4 | 1.40 ± 0.46 | ND
Lai et al. (2016); Monkeys, cynomolgus; N = 4-5 in PBMC and Bone Marrow; N = 6 in liver | | Liver | 2 | 0 | 15.46 ± 1.98 | ND
Lai et al. (2016); Monkeys, cynomolgus; N = 4-5 in PBMC and Bone Marrow; N = 6 in liver | | Liver | 2 | 7.4 | 11.80 ± 2.21 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | 0 (air control) or 18.5 mg/m^3^ [13CD2]-CH2O from PFA; 6 hrs/d; for 1,2, 4 d; whole-body exposure; PBMC, and bone marrow collected; tissue DNA extracted; dG-Me-Cys purified on HPLC and analyzed by nano-LC/ESI/MS-MS. | PBMC | 4 | 0 | 4.98 ± 0.61 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | PBMC | 1 | 18.5 | 3.26 ± 0.73 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | PBMC | 2 | 18.5 | 3.00 ± 0.98 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | PBMC | 4 | 18.5 | 7.19 ± 1.73 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | Bone Marrow | 4 | 0 | 1.64 ± 0.49 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | Bone Marrow | 1 | 18.5 | 1.80± 0.47 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | Bone Marrow | 2 | 18.5 | 1.84± 0.61 | ND
Lai et al. (2016); Rats, F344; N = 4-5 | | Bone Marrow | 4 | 18.5 | 1.58± 0.38 | ND

Abbreviations: PFA, paraformaldehyde; LC, liquid chromatography; MS, mass spectrometry; HPLC, high performance liquid chromatography; CH_2_O, formaldehyde; DPX, DNA-protein crosslinks; dG-Me-Cys, deoxyguanosine-methyl-cysteine; PBMC, peripheral blood mononuclear cell; ESI, electron spray ionization.

### C.1.8 Conjugation, Metabolism, and Speciation of Formaldehyde Outside the POE

Were inhaled formaldehyde to reach the blood or distal tissues, the same factors described for POE effects, specifically those regarding metabolism, reactivity, and the role of endogenous formaldehyde, would be relevant to other tissues. However, the majority of formaldehyde that would have reached these systemic sites is expected to be in the form of methanediol which is not reactive with macromolecules.

### C.1.9 Elimination Pathways of Exogenous and Endogenous Formaldehyde

Elimination pathways of endogenous and exogenous pathways may not be different since all tissues contain surplus GSH and NAD^+^. Endogenous formaldehyde is oxidized by ADH3 to formate which is either eliminated as CO_2_ in the exhaled breath or used in the cellular macromolecular synthesis or excreted in urine. Similarly, the majority of inhaled formaldehyde is metabolized in the URT by conversion to formate. Further, part of it may be metabolized to CO_2_ or utilized in the 1C pool. Since the available evidence does not show significant amounts of exogenous formaldehyde being transported into blood, the subsequent clearance of any exogenous formaldehyde that does reach the blood should be similar to the handling of endogenous formaldehyde.

#### Excretion of formaldehyde

Inhalation exposure to formaldehyde has not been shown to cause significant changes to the tissue levels of formaldehyde in the nasal mucosa, the blood, or in the distal tissues. Thus, it is not expected that formaldehyde and formaldehyde metabolite content in excretion products would be altered by exposure. The data supporting this expectation are consistent in human and animal studies.

Formate levels have been detected in both unexposed as well as formaldehyde-exposed individuals. Gottschling et al. (1984) examined urinary formic acid levels of 35 veterinary medicine students working in an anatomy lab before exposure and within 2 hours following a 1-, 2-, or 3-week exposure to a mean formaldehyde concentration of <0.615 mg/m^3^. The authors did not observe significant changes in the pre- and postexposure levels of formic acid. Since co-exposure to methanol may also contribute to the metabolism and excretion of formate, the fact that no significant increase in urinary formate was seen even with that co-exposure further supports the conclusion that the formaldehyde exposure does not significantly increase formate excretion.

Heck et al. (1983) determined the relative contributions of various elimination pathways in F344 rats following inhalation exposure to 0.77 and 16.1 mg/m^3^ of ^14^C-formaldehyde. As shown in Table C-10, the percentages of radioactivity in various fractions appear to be similar between the two dose groups tested. Within 70 hours after a 6-hour formaldehyde exposure, nearly 40% of radioactivity from inhaled ^14^C-formaldehyde appeared to be eliminated via expiration, probably as ^14^CO_2_ (note that about 97% of inhaled formaldehyde is taken up by the URT); and ≈17 and 5% of radioactivity was eliminated in the urine and feces, respectively. Nearly 40% of radioactivity remained in the carcass, which is presumably due to both covalent binding and metabolic incorporation. Thus, in one form or another, 40% of the ^14^C from inhaled formaldehyde is not eliminated and is expected to persist in the tissue(s) for some time. Overall, the authors concluded that, in rats, the relative elimination pathways for the remaining 60% of the ^14^C are independent of exposure concentration and followed the pattern of elimination in the order of expired air > urine > feces.

Although not specifically demonstrated following exposure, assumptions based on the known distribution and metabolism of formaldehyde and its detoxification products allow for inferences to be drawn regarding how inhaled ^14^C reaches these elimination points. Approximately one-third of inhaled formaldehyde is estimated to be removed in the URT mucus (Schlosser, 1999). It is expected that the majority of this formaldehyde would be removed from the URT via mucociliary clearance and excreted in urine in various forms. A large amount of inhaled formaldehyde penetrating the mucociliary layer of the URT is metabolized in the nasal cavity, giving rise to formate, which can be excreted in urine. Part of this formate may also be further oxidized and eliminated in the exhaled breath as CO_2_. Some formaldehyde is incorporated into the 1C pool.

Table C-10 Summary of excretion study following exposure to formaldehyde by inhalation in rats

Reference and species | Treatment and analysis | Observations
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | 0.77 and 16.1 mg/m^3^ HCHO for 6 hrs; rats sacrificed 70 hrs after removal from exposure chamber; tissues, urine, feces collected; exhaled ^14^CO_2_ trapped in a solution of 5 M ethanolamine in 2-methoxyethanol and % radioactivity measured in LSC. | % Radioactivity (Mean ± SD) in various fractions
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | | Source of radioactivity | Air borne CH_2_O
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | | Source of radioactivity | 0.77 mg/m^3^ | 16.1 mg/m^3^
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | | Expired air: | 39.4 ± 1.45 | 41.9 ± 0.8
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | | Urine: | 17.6 ± 1.2 | 17.3 ± 0.6
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | | Feces: | 4.2 ± 1.5 | 5.3 ± 1.3
Heck et al. (1983); Rats, Fischer; Male, n = 4, mean ± SD = 210 g | | Tissues^a^ and carcasses: | 38.9 ± 1.2 | 35.2 ± 0.5

a Nasal mucosa, trachea, esophagus, lung, kidney, liver, intestine, spleen, heart, plasma, erythrocytes, brain, testes.

#### Levels of endogenous formaldehyde in exhaled human breath

It is important to understand the relative amount of formaldehyde that is produced by the body and released in expired breath versus the amount of formaldehyde in ambient air. Table C-11 summarizes six studies that attempted to measure endogenous formaldehyde in exhaled breath. All studies performed prior to 2010 are limited by their analytical methods, which are subject to interference from other ions and isotopes that have the same m/z ratio (m/z = 31) as formaldehyde (e.g., methanol, ethanol, and nitric oxide). Also, it was not possible to differentiate between exogenous and endogenous formaldehyde in exhaled breath because the study subjects inhaled room air containing formaldehyde (≈11 μg/m^3^ formaldehyde).

Table C-11 Measured levels of formaldehyde, methanol and ethanol in room air and exhaled breath

Study | Analytical method | Sample | Formaldehyde^c^ (m/z 31) μg/m^3^ | Methanol μg/m^3^ | Ethanol μg/m^3^
(Moser et al., 2005)^a^; N = 344 | PTR-MS; DL: NR | Room air: | “Negligible” | “Negligible” | “Negligible”
(Moser et al., 2005)^a^; N = 344 | PTR-MS; DL: NR | Exhaled breath: | 5.24 (median); 1.49–89 (range) | 198 | NR
(Kushch et al., 2008); N = 370 | PTR-MS; DL: NR | Room air: | NR | NR | NR
(Kushch et al., 2008); N = 370 | PTR-MS; DL: NR | Exhaled breath: | 6.39 (median, nonsmokers); 5.53 (median, 81 smokers) | 241 (median, nonsmokers) | NR
(Cap et al., 2008)^b^; N = 34 | SIFT-MS; DL: 3.68 μg/m^3^ or better | Room air: | 11.79 ± 1.84 | NR | NR
(Cap et al., 2008)^b^; N = 34 | SIFT-MS; DL: 3.68 μg/m^3^ or better | Exhaled breath: | 2.46 (mean); 1.23 (median); 0–14.74 (range); 0 and 3.68 in 2 smokers | 365 (mean); 232 (median); 125–2,848 (range) | 549 (mean); 101 (median); 33–12,604 (range)
(Turner et al., 2008); N = 5 | SIFT-MS; DL: 6.14 μg/m^3^ or better | Room air: | ND | NR | NR
(Turner et al., 2008); N = 5 | SIFT-MS; DL: 6.14 μg/m^3^ or better | Exhaled breath: | ND | 617 (mean) | 549 (mean)
(Wang et al., 2008); N = 3 | SIFT-MS; DL: NR | Room air: | 11.05 ± 3.68 | 54 ± 11 | 124 ± 63
(Wang et al., 2008); N = 3 | SIFT-MS; DL: NR | Exhaled breath: | 6.51 (mean); 4.91–8.6 (range) | 329 (mean) | 185.46 (mean)
(Riess et al., 2010); N = 8 (nonsmokers); N = 2 (smokers) | Acac method; DL: <0.62 μg/m^3d^ | Charcoal filtered air: | 0 | NR | NR
(Riess et al., 2010); N = 8 (nonsmokers); N = 2 (smokers) | Acac method; DL: <0.62 μg/m^3d^ | Exhaled breath: | <0.62 (nonsmokers), ND; <0.62 (2 smokers), ND | NR | NR
(Riess et al., 2010); N = 8 (nonsmokers); N = 2 (smokers) | PTR-MS^e^; DL: ≈0.62 μg/m^3^ | Charcoal filtered air: | 0 | NR | NR
(Riess et al., 2010); N = 8 (nonsmokers); N = 2 (smokers) | PTR-MS^e^; DL: ≈0.62 μg/m^3^ | Exhaled breath: | 1.84 (mean; 0.86–2.82), nonsmokers.; 1.23–2.82, 2 smokers | NA | NA

Abbreviations: DL = Detection Limit; NR = Not Reported; ND = Not Detected; NA = Not Applicable; PTR-MS = Proton Transfer Reaction Mass Spectrometry; SIFT-MS −= Selected Ion Flow Tube Mass Spectrometry.

a Authors reported room air concentrations for 179 chemicals were “negligible.” No smoker data were provided.

b Smoker data and formaldehyde ambient concentration provided by Dr. Španĕl (personal communication).

c Values of formaldehyde in parts per billion (ppb) are converted as μg/m^3^ = ppb × 30 (m.w.)/24.45 or ppb × 1.23.

d The acac method’s limit of detection is 0.062 μg formaldehyde/m^3^, but the authors calculated a detection limit of 0.62 μg/m^3^ due to a slight periodically fluctuating background noise signal.

e After subtraction for methanol and NO product ions.

Riess et al. (2010), employed the acetyl acetone (acac) method^6^ to measure formaldehyde. This method is superior to the PTR-MS method used in previous studies because it has a lower limit of detection, exhibits no interference from other exhaled chemicals, and possesses the ability to measure formaldehyde in dry or humid atmospheres. In addition, volunteers inhaled formaldehyde-free air. For comparison, (Riess et al., 2010) used both the acac method and the PTR-MS method and observed mean exhaled formaldehyde concentrations of 1.84 µg/m^3^ in nonsmokers and 1.23–2.82 µg/m^3^ in smokers by the PTR-MS method, but no detectable formaldehyde in any subjects (including smokers) at baseline by the formaldehyde-specific acac method (see Table C-11). A concentration of 5.13 µg/m^3^ was detected by the acac method in a single smoker who was asked to smoke two cigarettes immediately before the measurement. This smoker’s formaldehyde level declined below the level of detection within 30 min. Formaldehyde levels were 1.47 to 2.09 µg/m^3^ in subjects asked to consume methanol-rich hard fruit liquor within 48 hours of the test (recall that methanol is metabolized by alcohol dehydrogenase to formaldehyde throughout the body). So, even when formaldehyde levels were intentionally elevated, very little endogenous formaldehyde was expelled in exhaled breath and these elevations were transient.

In summary, Riess et al. (2010), the only study to date which avoided the limitations of previous studies, demonstrated that if endogenous formaldehyde exists in exhaled breath, it is usually below their level of detection of <0.62 µg/m^3^.

### C.1.10 Conclusions Regarding the Toxicokinetics of Inhaled Formaldehyde Outside of the POE

In summary, the published data demonstrate that endogenous formaldehyde blood levels across species are approximately 0.1 mM and these levels do not change with exogenous formaldehyde exposure, arguing that inhaled formaldehyde is not absorbed into blood. One limitation of these studies is that these detection methods did not provide a clear distinction on the nature of formaldehyde (e.g., free, reversibly, or irreversibly bound, measured as formate, or part of the 1C pool). Formaldehyde inhalation studies show metabolic incorporation, but not covalent binding (e.g., hm-DNA adducts and DPXs) in bone marrow of rats which conclusively show that exogenous formaldehyde is not transported to distal tissues. Formaldehyde is likely to be metabolized in a similar way in distal tissues since the enzymes required for metabolism are expressed in all tissues. Endogenous levels of formaldehyde in exhaled breath analyzed by different research groups are often limited due to the lack of specificity in analytical methods and confounding by the presence of formaldehyde in room air in these studies. Based on a recent improved method, endogenous formaldehyde concentrations in exhaled air have been detected to be lower than the study’s detection limit of 0.62 μg/m^3^ outside of exceptional circumstances (just after smoking two cigarettes or ingesting something with a high level of methanol).

### C.1.11 Toxicokinetics Summary

Formaldehyde is an endogenous chemical produced intracellularly by enzymatic and nonenzymatic pathways during normal cellular metabolism, and a relatively small fraction of free formaldehyde is produced from metabolism of xenobiotics. Studies in experimental animals using direct and indirect measurements and modeling studies in human subjects have clearly shown that a majority of inhaled formaldehyde is rapidly absorbed in the URT despite anatomical and physiological differences across species. Inhaled formaldehyde develops a concentration gradient with an anterior to posterior distribution in the nasal cavity. High concentrations of formaldehyde are distributed to squamous, transitional, and respiratory epithelia; less formaldehyde uptake occurs in the olfactory epithelium, and very little or no formaldehyde reaches the lower respiratory tract, except possibly at very high exposure concentrations and/or during periods of high exertion with oronasal breathing. Studies in rats show that a single exposure to high levels of formaldehyde or repeated exposure to varying concentrations does not appreciably change the tissue levels of formaldehyde over the endogenous levels in the nasal mucosa.

Inhaled formaldehyde entering the nasal cavity interacts with the mucociliary apparatus which is the first line of defense. The majority of formaldehyde is rapidly converted to methanediol (≈99.9%), with a minor fraction (≈0.1%) remaining as free formaldehyde in the nasal mucus. A rapid equilibrium is assumed such that the 99.9:0.1% ratio is maintained at all times. Methanediol penetrates the tissues while free formaldehyde reacts with macromolecules. Uncertainties remain about the distribution of formaldehyde to underlying epithelium owing to the presence of endogenous formaldehyde, which is a component of normal cellular metabolism. Formaldehyde is metabolized to formate predominantly by ADH3 and by a minor pathway involving mitochondrial ALDH2. Formate can either enter the one-carbon pool leading to protein and nucleic acid synthesis or is further metabolized to CO_2_ and eliminated in expired air or excreted in urine unchanged.

Formaldehyde can interact with macromolecules either noncovalently (GSH, THF) or covalently (DPX, DDX, hm-DNA monoadducts, protein adducts). In rats and monkeys, DPXs show a dose-response to formaldehyde inhalation exposure in the nasal cavity where DPX distribution corresponds to tumor sites (rats) and cell proliferation (rats and monkeys), suggesting that DPX may be a good biomarker of exposure. Formaldehyde also induces a concentration-dependent increase in DNA monoadducts (e.g., N^2^-hm-dG adducts) in the nasal passages of monkeys and rats which can be distinguished from endogenous adducts using improved analytical methods. Higher levels of endogenous N^2^-hm-dG adducts are detectable than exogenous monoadducts, except at the highest inhaled exposure concentrations.

The toxicokinetics of formaldehyde may be influenced by certain formaldehyde-induced effects, such as modifications to mucociliary clearance, reflex bradypnea (rodents only) and reduction in minute volume, and dynamic tissue remodeling (e.g., squamous metaplasia), which have the potential to modulate formaldehyde uptake and clearance. For example, inhaled formaldehyde induces mucostasis and ciliastasis in the rat nasal mucociliary apparatus extending from anterior to posterior regions of the nasal cavity depending on the concentration and duration of exposure. Thus, at least at higher concentrations (e.g., at low concentrations, formaldehyde does not clearly cause mucostasis), estimates of tissue formaldehyde levels may be more uncertain. Similarly, the differences observed in altered minute volumes in rats and mice during repeated inhalation exposure to formaldehyde may impact dosimetric adjustment if extrapolated to humans.

Endogenous blood formaldehyde levels average around 0.1 mM across different species and inhalation exposure to formaldehyde does not alter blood formaldehyde levels, suggesting that inhaled formaldehyde is not significantly absorbed into blood. Formaldehyde-induced exogenous DNA monoadducts were detectable in nasal tissues but not in distal tissues of experimental animals exposed by inhalation. This argues against systemic transport of formaldehyde to distal tissues. Also, formaldehyde inhalation studies show metabolic incorporation, but not covalent binding in bone marrow of rats, further supporting the lack of transport of formaldehyde (as opposed to metabolites of formaldehyde) to distal tissues.

Analysis of formaldehyde in exhaled breath can be confounded by interfering gases in the analytical techniques used or can be confounded by the presence of formaldehyde in the room air. With improved techniques, endogenous formaldehyde concentrations in exhaled air have been detected to be usually lower than the past detection limit of 0.62 μg/m^3^. Overall, no evidence is available to indicate that inhaled formaldehyde is systemically transported.

### C.1.12 Modeling Formaldehyde Flux to Respiratory Tract Tissue

Formaldehyde is highly reactive and water soluble, thus its absorption in the mucus layer and tissue lining of the respiratory tract is known to be significant. This absorption is highly regional, and the absorption patterns differ substantially across species. This section first provides the motivation for developing detailed dosimetry models for the regional and species-specific absorption of formaldehyde. It then discusses the computation of inhaled formaldehyde transport in the upper (nose and mouth) and lower (lung and trachea) respiratory tract using fluid dynamic models and evaluates the level of confidence in these predictions. Finally, a revised dosimetry model that incorporates estimates of endogenous formaldehyde is discussed.

#### Species differences in anatomy: consequences for gas transport and respiratory tract lesions

The regional dose of inhaled formaldehyde in the epithelial lining of the respiratory tract of a given species depends on the amount absorbed at the airway-tissue interface, water solubility, mucus-to-tissue phase diffusion, and chemical reactions, such as hydrolysis, protein binding, and metabolism, and on the amount of formaldehyde delivered by the inhaled air to the tissue lining. This is a function of the major airflow patterns, air-phase diffusion, and absorption at the airway-epithelial tissue interface. Formaldehyde-induced squamous cell carcinomas (SCC) and other lesions that occur in the rat and monkey nasal passages and in the monkey lower respiratory tract are seen to be localized, with the lesion distribution patterns also showing species-specificity. It has been argued that the main determinant of these patterns and their differences among species is regional dose (Morgan et al., 1991; Monticello and Morgan, 1994; Monticello et al., 1996; Bogdanffy et al., 1999).

The anatomy of the respiratory tract, in particular the upper part (Figure C-7), and airflow patterns in this region (Figure C-8) show large differences across species. Furthermore, because of the convoluted nature of the airways (Figure C-7), the uptake of reactive and water-soluble gases such as formaldehyde in the upper respiratory tract (as seen in various simulations, Figure C-9) is highly nonhomogeneous over the nasal surface. Thus, as shown in Figure C-9, the spatial distribution of formaldehyde flux also shows strong species dependence. These observations, when juxtaposed with the localized occurrence of lesions, suggest that regional dose may be important in reducing uncertainty when extrapolating risk-related dose across species. Kimbell et al. (1993); Kepler et al. (1998), and Subramaniam et al. (1998) developed anatomically realistic finite-element representations of the noses of F344 rats, rhesus monkeys, and humans, and used them in physical and computational models (Kimbell et al., 2001a; Kimbell et al., 2001b); Figures C-7, C-8, C-9). This assessment uses dosimetry derived from these representations.

Formaldehyde dosimetry in the lower human respiratory tract (i.e., in the trachea and lung) may also be important to consider. The upper respiratory tract is generally a good scrubber of formaldehyde; as a result, there is less penetration into the lungs. However, the extent of this scrubbing varies among species. The rat upper respiratory tract is extremely efficient with only about 3% fractional penetration to the lower respiratory tract (Morgan et al., 1986a); however, penetration to the lung appears to be higher in the rhesus monkey (Figure C-9). Accordingly, while frank effects were seen only in the upper respiratory tract in rodents, DPX lesions induced by exposure to 6 ppm formaldehyde were also present in the major bronchiolar region of the rhesus monkey whose respiratory tract morphology is somewhat similar to the human (see Figure C-7). Another factor is that humans are oronasal breathers, with a significant fraction of the population breathing normally through the mouth (Niinimaa et al., 1981), while rats are obligate nose-only breathers. Oronasal breathing implies a much higher dose to the lower respiratory tract, particularly at higher activity profiles [see Figure C-11 and (Niinimaa et al., 1981)]. For all these reasons, the cancer dose-response assessment based upon nasal tumors observed in the F344 rat includes an additional exercise involving the human lung, even though the lung is not identified as a target organ in the hazard assessment. The dose-response section evaluates the extent to which human risk estimates increase when formaldehyde dose to the lower human respiratory tract is also considered. The dosimetry modeling for this purpose uses an idealized single-path model of the lower respiratory tract developed by (Overton et al., 2001).

Figure C-7 Reconstructed nasal passages of F344 rat, rhesus monkey, and human

Note: The nostril is to the right, and the nasopharynx is to the left. The right side shows the finite element mesh. The left-hand side shows tracings of airways obtained from cross sections of fixed heads (F344 rat and rhesus monkey) and magnetic resonance image sectional scans (humans). Aligned cross sections were connected to form a three-dimensional reconstruction and finite-element computational mesh.

Source: Adapted from Kimbell et al. (2001b). Additional images provided courtesy of Dr. J.S. Kimbell, CIIT Hamner Institutes.

Figure C-8 Illustration of interspecies differences in airflow and verification of CFD simulations with water-dye studies

Note: Panels A and B show the simulated airflow pattern versus water-dye streams observed experimentally in casts of the nasal passages of rats and monkeys, respectively. Panel C shows the simulated inspiration airflow pattern, and the histogram depicts the simulated axial velocities (white bars) versus experimental measurements made in hollow molds of the human nasal passages. Dye stream plots were compiled for the rat and monkey over the physiological range of inspiration flow rates. Modeled flow rates in humans were 15 L/min.

Source: Adapted from Kimbell et al. (2001b).

Figure C-9 Lateral view of nasal wall mass flux of inhaled formaldehyde simulated in the F344 rat, rhesus monkey, and human

Note: This is a rendering of a three-dimensional surface. Nostrils are to the right. Simulations were exercised in each species at steady-state inspiration flow rates of 0.576 L/min in the rat, 4.8 L/min in the monkey, and 15 L/min in the human. Flux was contoured over the range from 0–2,000 pmol/(mm^2^-hour-ppm) in each species.

Source: Kimbell et al. (2001b).

Figure C-10 Lateral view of nasal wall mass flux of inhaled formaldehyde simulated at various inspiratory flow rates in a human model

Note: This is a rendering of a three-dimensional surface, showing the right lateral view. Uptake is shown for the nonsquamous portion of the epithelium. The front portion of the nose (vestibule) is lined with keratinized squamous epithelium and is expected to absorb relatively much less formaldehyde.

Source: Kimbell et al. (2001a).

#### Modeling formaldehyde uptake in nasal passages

Anatomical reconstruction and tissue types: The dose-response modeling results evaluated and used in this document are based on several published computational models for air flow and formaldehyde uptake in the nasal passages of a F344 rat^7^, rhesus monkey, and human, and in the human lung (Subramaniam et al., 1998; Overton et al., 2001; Kimbell et al., 1993; Kimbell et al., 2001b; Kepler et al., 1998). The anatomical reconstructions for both computational and physical models were based on tracings of airways obtained from cross sections of fixed heads (F344 rat and rhesus monkey) and magnetic resonance image sectional scans (human).

Formaldehyde-induced nasal SCCs in rats are observed to arise only from respiratory or transitional epithelial cells in F344 rats and thought to be associated with the transformation of these cell-types to a squamous epithelial type due to exposure to formaldehyde (Morgan et al., 1986a). Therefore, the dosimetry calculations in (Kimbell et al., 2001b) focused on predicting the wall mass flux of formaldehyde (rate at which mass of formaldehyde is transported to unit area of the nasal or lung lining prior to disposition within the body—mass/[area-time]) to regions lined by respiratory or transitional epithelium and excluding squamous epithelial cells. An additional distinction was made regarding these regions. Formaldehyde hydrolyses in water and reacts readily with a number of components of nasal mucus and was therefore assumed to be absorbed at a higher rate by epithelial lining coated with mucus. The approximate locations of mucus-coated and nonmucus coated respiratory/transitional epithelial cells were mapped onto the reconstructed nasal geometry of the computer models. Types of nasal epithelium overlaid onto the geometry of the models were assumed to be similar in characteristics across all three species (rat, monkey, and human) except for thickness, surface area, location, and the extent of the nasal surface not coated by mucus. These characteristics were estimated from the literature or by direct measurements (Conolly et al., 2000; CIIT, 1999).

The fluid dynamics modeling in the respiratory tract comprises two steps: (1) model airflow through the airway lumen (solution of Navier-Stokes equations) and (2) using these solutions of the airflow field as input, model formaldehyde flux to the respiratory tract lining (solution of convective-diffusion equations). The local formaldehyde flux at the airway-to-epithelial tissue interface was assumed to be proportional to the air-phase formaldehyde concentration adjacent to the nasal lining. The proportionality constant is the mass transfer coefficient for the tissue phase, specified as boundary conditions on the solutions, and takes different values in the model depending on whether the tissue is coated with a mucus layer (k_m_) or not (k_nm_). Epithelium not coated with mucus was considered similar to epidermal tissue, and a value available from the literature for such tissue was used for k_nm_. On the other hand, Kimbell et al. determined k_m_ empirically for the rat by fitting the overall nasal uptake predicted by the CFD model to the average experimental values obtained by (Morgan et al., 1986a). The values of k_m_ and k_nm_ depend only on the solubility and diffusivity of the gas in the tissue, the thickness of the tissue, and the reaction rate of the gas (Hanna et al., 2001). Tissue thickness varies across species, but because formaldehyde is highly reactive and soluble, the primary kinetic determinant of interspecies differences in the net mass transfer rate is likely the difference in air-phase resistance and not tissue thickness. Therefore, (Kimbell et al., 2001b) assumed that values for the tissue phase mass transfer coefficients were the same for the human. EPA judges this assumption to be reasonable. The air-phase resistance (which is the inverse of the air-phase mass transfer coefficient) on the other hand would vary substantially between the rat and human on account of the substantial interspecies variations in airway geometry and airflow discussed earlier. Details of the boundary conditions for air flow and mass transfer, are provided in (Kimbell et al., 1993; Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) and (Subramaniam et al., 1998).

For the rat, minute volumes were allometrically scaled to 0.288 L/minute for a 315 g rat (Mauderly, 1986), and simulations were carried out at the steady-state unidirectional inspiratory rate of 0.576 L/min. For the human, simulations were carried out at the steady-state unidirectional inspiratory rate of 15, 18, 50, and 100 L/min, corresponding to half of the values for the minute volumes associated with the activity patterns of sleeping, sitting, and light and heavy exercise, respectively (ICRP, 1994). Because formaldehyde is highly water soluble and reactive, (Kimbell et al., 2001b) assumed that uptake occurred only during inspiration. Thus, for each breath, flux into nasal passage walls (rate of mass transport in the direction perpendicular to the nasal wall per mm^2^ of the wall surface) was assumed to be zero during exhalation, with no backpressure to uptake built up in the tissues. Overton et al. (2001) estimated the error due to this assumption to be small, roughly an underestimate of 3% in comparison to cyclic breathing. Inspiratory airflow was assumed to be constant in time (steady state). Subramaniam et al. (1998) considered this to be a reasonable assumption during resting breathing conditions based on a value of 0.02 obtained for the Strouhal number. Unsteady effects are insignificant when this number is much less than one. However, this assumption may not be reasonable for light and heavy exercise breathing scenarios.

Kimbell et al. (2001b) partitioned the nasal surface by flux to facilitate the use of local formaldehyde dose in dose-response modeling. Each of the resulting 20 “flux bins” was comprised of elements of the nasal surface that receive a particular interval of formaldehyde flux per ppm of exposure concentration (Kimbell et al., 2001b). These elements were not necessarily contiguous. The spatial coordinates of elements comprising a particular flux bin were fixed for all exposure concentrations, with formaldehyde flux (pmol/(mm2-hour) in a bin scaling linearly with exposure concentration (ppm), and therefore often expressed in terms of flux per ppm, that is, pmol/(mm^2^-hour-ppm).

Mass flux was estimated for the rat, monkey, and human over the entire nasal surface and over the portion of the nasal surface that was lined by nonsquamous epithelium (lateral wall mass flux shown in Figure C-9). Formaldehyde flux was also estimated for the rat and monkey over the areas where cell proliferation measurements were made (Monticello et al., 1989; Monticello et al., 1991) and over the anterior portion of the human nasal passages that is lined by nonsquamous epithelium. Maximum flux estimates for the entire upper respiratory tract were located in the mucus-coated squamous epithelium on the dorsal aspect of the dorsal medial meatus near the boundary between nonmucus and mucus-coated squamous epithelium in the rat, at the anterior or rostral margin of the middle turbinate in the monkey, and in the nonsquamous epithelium on the proximal portion of the mid-septum near the boundary between squamous and nonsquamous epithelium in the human (see (Kimbell et al., 2001a)) for tabulations of comparative estimates of formaldehyde flux across the species, for tabulations of comparative estimates of formaldehyde flux across the species. The rat-to-monkey ratio of the highest site-specific fluxes in the two species was 0.98. In the rat, the incidence of formaldehyde-induced SCCs in chronically exposed animals was high in the anterior lateral meatus [ALM, (Monticello et al., 1996)]. Flux (per ppm of inhaled concentration) at this site in the rat was similar to that predicted near the anterior or proximal aspect of the inferior turbinate and adjacent lateral walls and septum in the human, with a rat-to-human ratio of 0.84.

#### Formaldehyde Uptake in The Lower Respiratory Tract

Unlike the nasal passages, the human lower respiratory tract lends itself to a more simplified or idealized rendering. The one-dimensional (known as a “single-path” model) rendering of the human lung anatomy by Weibel (1963), which captures the geometry of the airways in an average or homogeneous sense for a given lung depth, is generally considered adequate unless the fluid dynamics at locations of airway bifurcations need to be explicitly modeled. Such an idealization of lung geometry has been successfully used in various models for the dosimetry of ozone and particulate and fibrous matter.^8^ The single-path model was used to calculate formaldehyde uptake in the human lower respiratory tract (Overton et al., 2001; CIIT, 1999). These authors applied a one-dimensional equation of mass transport to each generation of an adult human symmetric, bifurcating Weibel-type respiratory tract anatomical model. In order to achieve consistency with the inhaled output from the CFD model of the upper respiratory tract in (Subramaniam et al., 1998; Overton et al., 2001) augmented their model with an idealized upper respiratory tract and constrained their one-dimensional version of the nasal passages to have the same inspiratory air-flow rate and uptake during inspiration as the CFD simulations.

Figure C-11 Single-path model simulations of surface flux per ppm of formaldehyde exposure concentration in an adult male human

Source: Overton et al. (2001).

The primary predictions (Figure C-11) of the model were: more than 95% of the inhaled formaldehyde is retained; formaldehyde flux in the lower respiratory tract increases for several lung airway generations relative to flux in posterior-most segment of the nose; with further increase in lung depth, formaldehyde flux decreases rapidly resulting in almost zero flux to the alveolar sacs. (Overton et al., 2001) also modeled uptake at high inspiratory rates. At a minute volume of 50 L/minute^9^ formaldehyde flux in the mouth cavity is comparable (but a bit less) to that occurring in the nasal passages (Figure C-11).^10^

#### Level of confidence in formaldehyde uptake simulations

As mentioned earlier, the computational fluid dynamics simulations involved two steps, and the confidence in each step is addressed separately below.

##### Confidence in predicted airflow profiles

To verify the CFD simulations of nasal airflow profiles, the authors constructed physical models from the finite-element reconstructions used in the computational models. The simulated streamlines of steady-state inspiration airflow predicted by the CFD model agreed reasonably well with experimentally observed patterns of water-dye streams made in casts of the nasal passages for the rat and monkey as shown in panels A and B in Figure C-8. The airflow velocity predicted by CFD model simulations of the human also agreed well with measurements taken in hollow molds of the human nasal passages (panel C, Figure C-8) (Subramaniam et al., 1998; Kimbell et al., 1993; Kimbell et al., 1997b; Kepler et al., 1998). However, the accuracy and relevance of these comparisons are limited. Because the airflow profiles were verified by only a simple video analysis of dye streak lines observed in the physical molds this method can be considered reasonable for only the major airflow streams. For the human, axial airflow velocities were also measured experimentally in a physical cast, and these compared well with CFD simulations (panel C, Figure C-8). However, the physical model used for the velocity measurements corresponds to that of a different individual than the one for which the CFD simulations were carried out.

Another verification comes from measuring pressure gradients across the nasal cavity. Plots of pressure drop versus volumetric airflow rate predicted by the CFD simulations compared well with measurements made in rats in vivo (Gerde et al., 1991) and in acrylic casts of the rat nasal airways (Cheng et al., 1990) as shown in Figure C-12. This latter comparison remains qualitative due to differences among the simulation and experiments as to where the outlet pressure was measured and because no tubing attachments or other experimental apparatus were included in the simulation geometry. The simulated pressure drop values were somewhat lower, possibly due to these differences.

Kimbell et al. (2001a) examined the extent to which their results were subject to errors in mass balance and applied ad-hoc corrections to compensate for these errors. Because airflow and uptake were simulated separately, they each contributed separately to the mass balance error; however, the error component due to airflow was minimal (< 0.4%). The percent overall uptake of formaldehyde was defined as 100% × (mass entering nostril – mass exiting outlet)/(mass entering nostril), and its mass balance error was calculated as 100% × (mass entering nostril – mass absorbed by airway walls – mass exiting outlet)/(mass entering nostril). For the rat, monkey, and human the mass balance errors associated with simulated formaldehyde uptake from air into tissue were less than 14% at resting minute volumes, and therefore, not a major concern, but these errors increased to 27% at the highest human inspiratory rate corresponding to exercise conditions. Kimbell (2001a) corrected for these errors by evenly distributing the lost mass over the entire nasal surface in their simulation results.

Figure C-12 Pressure drop versus volumetric airflow rate predicted by the CIIT CFD model compared with pressure drop measurements made in two hollow molds (C1 and C2) of the rat nasal passage (Cheng et al., 1990) or in rats in vivo (Gerde et al., 1991)

Source: Kimbell et al. (1997b).

##### Confidence in modeled flux estimates

Unlike the verification of the airflow simulations, it was not possible to evaluate the regional formaldehyde flux calculations directly; however, there are several indirect qualitative and quantitative lines of evidence that provide general confidence in the flux profiles predicted by (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) for the F344 rat nasal passages when the flux is averaged over gross regions of the nasal lining. This evidence is listed below.

In Kimbell et al. (2001b), the tissue-phase mass-transfer boundary conditions were set by fitting overall (whole nose) formaldehyde uptake at various exposure concentrations to the experimental data in Morgan et al. (1986a). Since this was the only data set available, it was not possible to independently verify the model results for overall uptake. However, results from earlier work by (Kimbell et al., 1993) are informative for this purpose because in this case the model was not calibrated by fitting model predictions to experimental data; instead, this model assumed an infinite sink for absorption at the nasal lining on account of the highly reactive and soluble nature of formaldehyde. Kimbell et al. (1993) predict 99% uptake of inhaled formaldehyde in the rat nose, which is slightly above the upper end of the range of 91–98% observed by (Morgan et al., 1986a). The utility of those simulations is however limited because the posterior portion of the nose was not included in the model, and the assumption of infinitely absorbing nasal walls makes the boundary condition less realistic than that used in (Kimbell et al., 2001b). Calculations based upon (Kimbell et al., 1993) are compared with various experimental observations below.

Morgan et al. (1991) showed general qualitative correspondence between the main routes of flow and lesion distribution induced by formaldehyde in the rat nose and hypothesized that the localized nature of the lesions must be related to the regional uptake of formaldehyde. This was borne out by (Kimbell et al., 1993) who described similarities in patterns of computed regional mass flux and lesion distribution due to formaldehyde. These authors reported on correlations in patterns in the coronal section immediately posterior to the vestibular region (as discussed earlier, the vestibular region is protected by keratinized epithelium and is therefore not likely to significantly absorb formaldehyde); simulated flux levels over regions where lesions were seen, such as the medial aspect of the maxilloturbinate and the adjacent septum, were an order of magnitude higher than over other regions where lesions were not seen, such as the nasoturbinate.^11^

A reasonable level of confidence in flux predictions by (Kimbell et al., 1993) is also attained indirectly by comparing experimental data on formaldehyde-DPX concentration in the F344 rat with modeled results in (Cohen Hubal et al., 1997); these authors used flux estimates generated by the CFD model in (Kimbell et al., 1993) in a physiologically based pharmacokinetic (PBPK) model for formaldehyde-DPX concentration in the F344 rat. This hybrid CFD-PBPK model was calibrated by optimizing model predictions of DPX concentrations against DPX collected over the entire nose in separate experiments by (Casanova et al., 1989; Casanova et al., 1991) on F344 rat noses exposed to formaldehyde at 0.3, 0.7, 2.0, 6.0, and 10 ppm. The nasal regions were then separated into two categories depending upon whether tumor incidence was high or low in a region, and model predictions of DPX concentrations were compared with the experimental data considered only from the high-tumor region, including additional DPX data from the high-tumor region at 15-ppm exposure concentration which had not been used in model calibration. The predictions are seen to compare well with experimental values (Figure C-13). Such a comparison is not available for the simulation of uptake patterns in the human.

Figure C-13 Formaldehyde-DPX dosimetry in the F344 rat

Panel A: calibration of the PBPK model using data from high and low tumor incidence sites. Panel B: model prediction compared against data from a high tumor incidence site. Dashed line in panel A shows the extrapolation outside the range of the calibrated data.

Source: Cohen Hubal et al. (1997).

##### Effect of reflex bradypnea on dosimetry

A source of uncertainty in the modeled human flux estimates arises because the value of the tissue-phase mass-transfer coefficient used as a boundary condition in human simulations is the same as that obtained from calibration of the rat model. As explained earlier, qualitatively this appears reasonable; however, EPA is unable to quantitatively evaluate the impact of this uncertainty.

The CFD simulations do not model reflex bradypnea, a protective reflex observed in rodents. As discussed at length in Appendix C-2, it is reasonable to expect a range of 25% (Chang et al., 1983) to 45% (Barrow et al., 1983) decrease in minute volume in F344 rats at the exposure concentration of 15 ppm. Explicit omission of this effect in the modeling is, however, not likely to be a source of major uncertainty in the modeled results for uptake of formaldehyde in the rat nose for the following reason: the CFD model for the F344 rat was calibrated to fit the overall experimental results for formaldehyde uptake in the F344 rat at a 15 ppm exposure concentration by adjusting the mass transfer coefficient used as boundary condition on the absorbing portion of the nasal lining. Thus, any reflex bradypnea occurring in those experimental animals is implicitly factored into the value used for the boundary condition. Nonetheless, some error in the localized distribution of uptake patterns may be expected, even if the overall uptake is reproduced correctly.

#### Modeling Interindividual Variability in the Nasal Dosimetry of Reactive and Soluble Gases

Lorenti Garcia et al. (2009) used computational fluid dynamics to study human variability in the nasal dosimetry of reactive, water-soluble gases in 5 adults and 2 children, aged 7 and 8 years. The authors considered two model categories of gases, corresponding to maximal and moderate absorption at the nasal lining. We focus here only on the “maximal uptake” simulations in (Lorenti Garcia et al., 2009); note that this term for the simulations does not correspond to regions of maximum flux but rather characterizes the gas category. In this case, the gas was considered so highly reactive and soluble that it was reasonable to assume an infinitely fast reaction of the absorbed gas with compounds in the airway lining. Although such a gas could be reasonably considered as a proxy for formaldehyde, these results cannot be fully utilized to inform quantitative estimates of formaldehyde dosimetry (and does not appear to have been the intent of the authors either). This is because the same boundary condition corresponding to maximal uptake was applied on the vestibular lining of the nose as well as on the respiratory and transitional epithelial lining on the rest of the nose. This is not appropriate for formaldehyde as the lining on the nasal vestibule is made of keratinized epithelium which is considerably less absorbing than the rest of the nose (Kimbell et al., 2001a).

Lorenti Garcia et al. (2009) concluded that overall uptake efficiency, and average and maximum flux levels over the entire nasal lining did not vary substantially between adults (1.6-fold difference in average flux and much less in maximum flux), and the mean values of these quantities were comparable between adults and children. These results are also in agreement with conclusions reached by (Ginsberg et al., 2005) that overall extrathoracic absorption of highly and moderately reactive and soluble gases [corresponding to Category 1 and 2 reactive gases as per the scheme in (U.S. EPA, 1994)] is similar in adults and children. On the other hand (Lorenti Garcia et al., 2009) state that their models predicted significant interhuman variability in flux levels at specific points on the nasal wall; Figure 6A of their paper (reproduced here as Figure C-14) indicates a 3- to 5-fold difference among the individuals in the study when flux was plotted as a function of distance from the nostrils normalized by the length of the septum. This observation needs to be accompanied by a caveat: because similar fluxes may correspond to different regions in individuals, it is possible that this spread in values overestimates the actual variability in local flux in these individuals.

Figure C-14 Flux of highly reactive gas across the nasal lining as a function of normalized distance from the nostril for 5 adults and 2 children

While the sample size in this study is too small to consider the results representative of the population as a whole, various comparisons with the characteristics of other study populations add to the strength of this study; for example, the surface area to volume ratio among the five adults ranged from 0.87 to 1.12 mm^−1^ which compared well with a result of 1.05 ± 0.23 obtained from measurements in 40 adult Caucasians (Yokley, 2009), and the surface area ranged from 16,683 to 23,219 cm^2^ which compared well with a result of 18,300 ± 2,200 cm^2^ obtained from measurements in 45 adults (Guilmette et al., 1997). It is useful to note here that the nasal anatomy reconstructed for modeling the dosimetry of formaldehyde in the human nose in (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) and discussed earlier was that of one of the individuals in the (Lorenti Garcia et al., 2009) study.

#### Models Estimating the Effects of Endogenous Formaldehyde on Dosimetry Predictions in Nasal Tissues

Schroeter et al. (2014) developed a hybrid toxicokinetic fluid dynamic model for predicting the uptake of inhaled formaldehyde that incorporates the production of endogenous formaldehyde in nasal tissue. EPA reviewed their calculations in detail. In this model, the predicted formation of endogenous formaldehyde leads to a baseline tissue level of formaldhyde in the nasal tissue. When formaldehyde is also inhaled, absorbed formaldehyde, along with endogenous formaldehyde, contributes to increasing predicted nasal tissue levels of formaldehyde (see Figure 4 of their paper).

However, these authors also interpret their results as showing a decrease in “percent net nasal uptake” of inhaled formaldehyde at low concentrations. EPA reviewed these calculations and finds them nontransparent and confusing to the reader. Due to endogenous formaldehyde production, the model of Schroeter et al. (2014) predicts a net desorption of formaldehyde at zero exposure. When formaldehyde is inhaled, the exhaled breath will represent the joint contributions of exhaled endogenous formaldehyde and an unabsorbed fraction of inhaled formaldehyde. Thus, what the authors term “percent net nasal uptake” [calculated as (inhaled formaldehyde - exhaled formaldehyde)/inhaled formaldhyde] conflates absorption of inhaled formaldehyde and release of endogenous formaldehyde. A more transparent understanding of their results can be obtained from Table 5 of the paper which provides estimates of formaldehyde flux into nasal tissue at different concentrations of inhaled formaldehyde. As an example, EPA examined the values shown for average tissue flux for humans. EPA found that for concentrations 0.1 ppm and below, the average human flux estimates (pmol/mm2-hr), were precisely linear with exposure concentrations (ppm):

Flux = − a + b × Conc, where a = 1.54 pmol / mm^2^ -hr , b = 1,500 pmol / mm^2^ -hr-ppm .

This can be understood as a positive contribution of inhaled formaldehyde in the amount of 1,500 pmol/mm2-hr per ppm superimposed on a negative (−1.54) flux out of the tissue due to loss of endogenously formed formaldehyde and is just the pattern that would be expected when the absorbed amount of inhaled formaldehyde is constant in the lower concentration range. Similar relationships can be fit to their results for other species as well as predictions for maximum flux rates. Schroeter et al. (2014) plotted flux versus exposure concentration on a log-log scale; EPA notes that the apparent “non-linearities” at low concentrations seen in Figure 5 of that paper are to be expected when a relationship with an intercept is plotted in this manner. In summary, any external exposure is predicted to cause some increase in the tissue concentration in this model, since a nonzero air concentration produces positive flux in the opposite direction of the efflux of endogenous formaldehyde. Therefore, the modeling results do not lead to an inference of nonlinearities in the flux of inhaled FA into nasal tissue at low concentrations. While the analysis of (Schroeter et al., 2014) represents an important first step towards incorporating the presence of endogenous formaldehyde into models estimating the flux (or uptake) of inhaled formaldehyde, several uncertainties in the underlying assumptions have yet to be addressed:

- The tissue levels of formaldehyde predicted by the model of (Schroeter et al., 2014) appear to be orders of magnitude in excess of the levels that would be consistent with the observed DPX levels (Heck et al., 1983) and formaldehyde-DNA binding rate (Heck and Keller, 1988).
- Endogenous formaldehyde levels were calculated based on blood concentrations. But (Heck et al., 1982) measured 12.6 µg/g total formaldehyde in rat nasal tissues and only 2.24 µg/g in rat blood (Heck et al., 1985). Based on DNA-adduct measurements, it appears that the majority of formaldehyde is bound to GSH in a manner that reduces its interaction with DNA and, presumably, other key macromolecules (see Appendix C.1.4). The extent of GSH-binding could significantly reduce diffusion across the epithelial cell membrane (i.e., between blood and nasal tissue), in which case blood concentrations may not correlate well with tissue concentrations.
- Since nasal tissue levels of formaldehyde are higher than blood levels, it is likely that these levels are produced by endogenous metabolism in situ, rather than entering the mucosa via diffusion from a “blood” layer at a specific depth from the mucosa-air surface, the latter being the assumption used by (Schroeter et al., 2014).
- While (Schroeter et al., 2014) did not report exhaled breath levels, their results indicate that uptake will exactly balance desorption in humans at about 1.23 µg/m^3^ (1.0 ppb), from which one might assume this is the level their model would predict in exhaled breath. In the study of (Riess et al., 2010), exhaled breath levels for nonsmokers were found to be below a detection limit of 0.62 µg/m^3^, which corresponds to 0.5 ppb at 20°C. While this is within a factor of two, an acceptable level of error for such an extrapolation, it is a further indication that the assumed level of free endogenous formaldehyde in the (Schroeter et al., 2014) model is too high.

Despite these limitations, the efforts by (Schroeter et al., 2014) highlight the fact that at sufficiently low levels of exogenous formaldehyde, the contribution of endogenous formaldehyde could become significant; accounting for this contribution would address a critical uncertainty for interpreting the uptake of inhaled formaldehyde. Additional studies addressing the potential contribution of endogenous formaldehyde are warranted. As a sensitivity analysis, EPA notes in Section 5.2.1 that the unit risk estimate for nasal cancers based on rat studies are not appreciably altered if calculated using the revised formaldehyde estimates from (Schroeter et al., 2014).

Campbell Jr et al. (2020) modified the original model by (Andersen et al., 2010) using exogenous and endogenous formaldehyde adduct data from (Leng et al., 2019) (28-day study of 6 hours/day exposures), (Yu et al., 2015b) (28-day study of 6 hrs/day exposures), and (Lu et al., 2010a; Lu et al., 2011) (a single 6-hour exposure). The following major changes were made to the original model:

a) The model simulates observed data for formaldehyde-induced DNA mono-adducts (N2-hydroxymethyl-dG). The previous models simulated formaldehyde-induced DNA-protein cross-links (DPX).
b) A zero-order term (VMMUC) was used to account for tissue clearance of inhaled formaldehyde. This is a restriction on uptake from the air phase to the tissue compartment.
c) The rate of production of endogenous formaldehyde (Kp) was increased to nearly double the original rate set by (Andersen et al., 2010). The maximum rate of formaldehyde oxidase metabolism (Vmax) was increased by over a factor of 10.

There are some notable observations from the data used in the modeling. Leng et al. (2019) showed no exogenous formaldehyde-induced DNA adducts in the nose at concentrations up to 0.3 ppm and no increase in endogenous formaldehyde-induced DNA adducts up to 0.3 ppm. (Lu et al., 2010a; Lu et al., 2011) observed an increase in exogenous formaldehyde adducts in rat nasal tissue starting at 0.7 ppm but no increase in endogenous adducts between 0.7 ppm–15 ppm (although there does appear to be a perturbation in the mean and variance of endogenous adducts in this range). The data at and above 0.7 ppm was used to re-optimize the cellular metabolic parameters. The data up to 0.3 ppm by (Leng et al., 2019) (which did not observe increased adducts) was used to visually optimize the parameter defining the lower limit on uptake (VMMUC). Because of the abrupt change in observed adduct levels between 0.3 ppm and 0.7 ppm there is model uncertainty within that concentration range and below the limit of detection.

Key results from this work add to our characterization of uncertainties related to endogenous formaldehyde levels and formaldehyde dose-response at low exposures. First, the model estimated a non-zero value for VMMUC, indicating that the inhalation rate must exceed the tissue clearance rate for formaldehyde to be absorbed by the tissue. The model was calibrated with the restriction that formaldehyde absorption in the nose occurs only at exposure concentrations above 0.3 ppm in the rat. Secondly, (Campbell Jr et al., 2020) assessed steady-state concentration of free endogenous formaldehyde to be 20 times lower than the value determined experimentally by (Heck et al., 1982) and 15 times lower than assessed by (Andersen et al., 2010). In (Campbell Jr et al., 2020), the estimate for free endogenous levels decreased from 0.31 mM to 0.020 mM and the basal concentration of endogenous formaldehyde bound to sulfhydryl increased from 0.057 to 0.12mM (2 times higher). Campbell Jr et al. (2020) attributed this discrepancy to the potential for the (Heck et al., 1982) measurement methodology to overestimate tissue formaldehyde levels.

The original model (Andersen et al., 2010) did not adequately fit these new data, and (Campbell Jr et al., 2020) justified changes to the (Andersen et al., 2010) model parameters for cellular metabolism on the grounds that data from (Heck et al., 1982) are biased due to the method used to measure tissue formaldehyde. However, it is possible that the cause of this model/data discrepancy is inadequate model structure rather than a bias in the original data. As a result, there is inherent model uncertainty in the revised model for cellular metabolism.

Extrapolation of results in (Campbell Jr et al., 2020) to humans is not possible because the data and the model are specific to rats.

## C.2 REFLEX BRADYPNEA

Reflex bradypnea (RB) is a protective reflex that allows laboratory rodents to minimize their exposure to upper respiratory tract (URT) irritants such as aldehydes, ammonia, isocyanates, and pyrethroids (Gordon et al., 2008). This reflex is initiated by stimulation of trigeminal nerve endings in the mucosa of the URT and the eyes. It is associated with the chemosensitive part of the nociceptive system—the common chemical sense that detects noxious airborne exposures (Nielsen, 1991).

### C.2.1 The signs of reflex bradypnea

RB is manifest by immediate decreases in the metabolic rate, CO_2_ production, and demand for oxygen. This is followed by rapid decreases in body temperature (i.e., hypothermia; as much as 11°C in rats and 14°C in mice; Figure C-15), activity, heart rate, blood pressure, respiratory rate (breaths/minute; Figure C-16), and minute volume (see Figure C-17). RB also results in decreased blood pO_2_ and pCO_2_ and increased blood pH (Pauluhn, 2008, 2018; OECD, 2009; Jaeger and Gearhart, 1982; Gordon et al., 2008; Chang and Barrow, 1984). Thus, the physiological effects and signs of RB may be misinterpreted as, for example, chemical-induced behavioral or developmental effects.

RB is regulated by a complex feedback response (Yokley, 2012). Gordon et al. (2008) demonstrated that the extent of RB depends on the concentration of the irritant (see Figure C-15). For example, after several hours of exposure to an isocyanate, mice exhibited concentration-dependent changes with those in the high concentration group presenting a mean body temperature of 23°C and approximately 90% decreases in respiratory rate and minute volume.

Figure C-15 Signs of Reflex Bradypnea

Left Panel: Concentration-related hypothermia in mice exposed to an isocyanate for 360 minutes. Note the gradual recovery in body temperature after exposure ceased. Right panel: Concentration-related decreases in respiratory rate in mice exposed to an isocyanate. Note the correlation between the curves for rectal temperature and respiratory rate over the course of 180 minutes.

Source: Gordon et al. (2008).

Figure C-16 An oscillograph that compares the respiratory cycle for mice exposed to an URT irritant (lower tracing) to an air control group (upper tracing)

The exposed animals have a characteristic pause before exhaling—a bradypneic period—which results in a net decrease in the respiratory rate (breaths/minute). Because the exposed group has a slightly greater tidal volume (height of the tracings) but a much lower respiratory rate, the net result is a lower minute volume and reduced exposure to the irritant.

Source: Kane and Alarie (1977).

Figure C-17 Formaldehyde effects on minute volume in naïve and formaldehyde-pretreated male B6C3F1 mice and F344 rats

Pretreated animals were exposed to 6.9 or 17.6 mg/m^3^ formaldehyde 6 hrs/d for 4 d. Note that the mice had a greater response than the rats, and the pretreated animals had a greater response than the naïve animals.

Source: Redrawn from Chang et al. (1983).

Figure C-17 demonstrates that the onset of RB after formaldehyde inhalation is immediate, with a marked decrease in minute volume in mice and rats minutes after exposure begins. Because reduced respiration lessens exposure to an irritating chemical, the toxicity is reduced and the animal’s survival is enhanced. This is important for the survival of rodents living in burrows and confined spaces that may not be able to avoid exposure. Figure C-15 (left panel) demonstrates that the effects of RB are reversible, but it can take several minutes to several hours for all physiological parameters to return to preexposure conditions, depending on the extent of hypothermia (Pauluhn, 2008, 2018; OECD, 2009; Jaeger and Gearhart, 1982; Barrow et al., 1983).

The physiological signs of RB in rodents can be striking, but they are not signs of toxicity and, as such, are not considered appropriate for defining an animal POD. Also, the signs of RB are not relevant to humans since humans cannot experience RB. RB can only occur in small animals such as mice and rats that can, because of their small size, rapidly lower their core body temperatures when their metabolic rate reflexively decreases. Even a mild decrease in body temperature can lessen the toxicity and metabolic activation of many chemicals, but it can also slow the excretion of toxicants. Overall, the protection from cellular toxicity afforded by RB-induced hypothermia outweighs the undesirable effect of a slower excretion rate (Gordon et al., 2008). Even though RB has been reported in the literature since the 1960s, it is largely unknown to most toxicologists. None of the rodent inhalation studies of formaldehyde, except for a few RB-specific studies, attempted to identify or measure RB, including measures of body temperature and respiration. As RB likely occurred in most, if not all, rodent inhalation toxicity studies involving high level exposures to formaldehyde, this uncertainty is acknowledged and discussed in the assessment, and for particular health outcomes it is specifically considered during study evaluation (e.g., see description below regarding behavioral effects, since RB can affect activity).

### C.2.2 Irritation, reflex bradypnea, and the RD_50_

A test for assessing sensory irritation was developed by Yves Alarie in the 1960s. In an Alarie test, rodent respiration is measured before, during, and after exposure to one or more concentrations of an irritant, and then respiratory depression (RD) is statistically quantified. RD is followed by a subscript that gives the percentage of respiratory depression (e.g., RD_0_, RD_20_, RD_50_, RD_70_, etc.) The most commonly reported value in Alarie tests is the RD_50_—the concentration of an irritating chemical that causes a 50% depression in the respiratory rate (Kane et al., 1979).

“Irritation” refers to two distinct processes. The first process is sensory irritation of nerve endings. URT irritation of the trigeminal nerve, which humans perceive as a burning or stinging sensation, is what triggers RB in rodents. The second process relates to an inflammatory response elicited by an irritating chemical, which is manifested by histopathologic changes such as local redness, edema, pruritus, and cellular alterations. Sensory irritation may prevent histopathologic damage through avoidance or through RB in rodents. Bos et al. (2002) found no correlation between chemical concentrations that cause sensory irritation (as measured by the Alarie test) and concentrations that induce histopathological changes. For a variety of irritants, the lowest concentration that induces nasal histopathologic lesions can range from 0.3 times the RD_50_ to more than 3 times the RD_50_.

Alarie tests are useful for (1) identifying chemicals which are URT sensory irritants, (2) quantifying irritating concentrations, and (3) ranking chemicals for their irritancy potential. Alarie (1981) proposed using 0.03 times the RD_50_ values to predict threshold limit values (TLVs: typically used to define workplace exposures that can be repeatedly encountered without adverse effects) for a variety of irritants. More recently, Nielsen et al. (2007) proposed the use of animal RD_50_ and RD_0_ values along with human data in a weight-of-evidence approach to predict acute or short-term TLVs, the RD_0_ being a threshold or NOEL for decreased respiratory rate.

Tables C-12 and C-13 present formaldehyde RD values from several Alarie studies for mice and rats, respectively.^12^ No RD values exist for female mice or rats. Across the literature, there is fairly good agreement on RD_50_ values for various strains of mice:

Table C-12 Formaldehyde respiratory depression (RD) values for several mouse strains and exposure durations

Study | Mouse strain | Exposure (min) | RD_50_ (mg/m^3^) | RD_10_ (mg/m^3^) | RD_0_ (mg/m^3^)
Kane and Alarie (1977) | ♂ Swiss-Webster | 10 | 3.8 | 0.5^a^ | 0.31^a^
Nielsen et al. (1999) | ♂ BALB/c | 10 | 4.9 | 0.4
Barrow et al. (1983) | ♂ B6C3F1 | 10 | 5.4 | 0.9* | 0.49*
Chang et al. (1981) | ♂ B6C3F1 | 10 | 6.0 | – | –
de Ceaurriz et al. (1981) | ♂ Swiss OF_1_ | 5 | 6.5 | – | –

a Value derived from a graph.

Figure C-17 shows that rats are less responsive to URT irritants than mice, which is why rats have higher RD_50_ values than mice.

Table C-13 Formaldehyde respiratory depression (RD) values for several rat strains and exposure durations

Study | Rat strain | Exposure (min) | RD_50_ (mg/m^3^) | RD_10_ (mg/m^3^) | RD_0_ (mg/m^3^)
Cassee et al. (1996a) | ♂ Wistar | 30 | 12.3 | – | –
Barrow et al. (1983) | ♂ F-344 | 10 | 16.1 | 1.2^a^ | –
Gardner et al. (1985) | ♂ Crl-CD | 15 | 17.0 | – | –
Chang et al. (1981) | ♂ F-344 | 10 | 39.0 | – | –

a Value derived from a graph.

### C.2.3 Tolerance

Nearly all rodent studies that assessed RB are acute Alarie tests lasting no more than a few minutes or hours. There are no long-term studies that investigated whether-or-when rodents develop a tolerance to formaldehyde or other irritants and eventually begin to breathe normally. Mouse studies are a particular concern because mice have a greater RB response than rats and are able to sustain bradypnea and hypothermia for a longer period than rats. The bulleted short-term (4 days to 4 weeks) studies below examined the potential for rodents to develop tolerance to formaldehyde and cyfluthrin. The formaldehyde studies show no sign of tolerance over 10 days of exposure at concentrations as high as 18 mg/m^3^, but what happens after 10 days remains unknown.

- Kane and Alarie (1977) observed a progressive decrease in respiratory rate (i.e., a progressively greater RB response) over 4 days of formaldehyde exposure in Swiss-Webster mice exposed to an RD_50_ of 3.8 mg/m^3^. A similar lack of tolerance was also seen in mice exposed to acrolein (an aldehyde) at an RD_50_ of 3.9 mg/m^3^.
- Chang et al. (1983) exposed mice and rats to 6.9 or 17.6 mg/m^3^ formaldehyde (two of the concentrations used in the Battelle carcinogenicity study) 6 hours/day for 4 days. On day 4, both mice and rats showed concentration-related decreases in respiratory rate and minute volume, but the decreases in mice were markedly greater (see Figure A-20).
- Chang and Barrow (1984) observed no tolerance in F-344 rats exposed to 18 mg/m^3^ formaldehyde for 10 days. Tolerance was observed in rats exposed over 4 days to a very high formaldehyde concentration of 34 mg/m^3^, likely due to destruction or downregulation of sensory trigeminal nerve endings or receptors, respectively.
- Pauluhn (1998) exposed Wistar rats 6 hours/day, 5 days/week for 4 weeks to cyfluthrin, a pyrethroid URT irritant, at the acute RD_50_ concentration of 47 mg/m^3^. Mean decreases in respiratory rate were 45% at week 2 and 55% at week 4, that is, there was no sign of tolerance. Since formaldehyde and cyfluthrin are both URT irritants, it is likely that similar results might be seen with formaldehyde.

### C.2.4 Reflex bradypnea and interpreting health effects data

Current testing guidelines do not require examination of RB-related endpoints and reduced inhaled rodent exposure may complicate interpretations regarding inferences of potential human risk. For example, Battelle’s carcinogenicity study illustrates an apparent role of RB in long-term studies. The study authors observed a disparity in formaldehyde-induced squamous metaplasia and inflammation between B6C3F1 mice and F-344 rats. Both species were identically exposed in whole-body chambers at analytical concentrations of 0, 2.5, 6.9, or 17.6 mg/m^3^. At comparable concentrations, nasal lesions were much less severe in mice than in rats. In fact, incidences of squamous cell carcinoma were similar in rats exposed at 6.9 mg/m^3^ and in mice exposed at 17.6 mg/m^3^—a difference in concentration of more than 2-fold (Kerns et al., 1983). Kerns et al. reasoned this 2-fold difference between mice and rats may be due to “their physiological responses to formaldehyde inhalation,” that is, due to RB. To support their hypothesis, they cited a 4-day Alarie test by (Chang et al., 1983) described in the bullet above, in which the reduction in minute volume was 2-fold greater in mice than in rats when exposed at 17.6 mg/m^3^ (see Figure C-17). In other words, the rats exposed at 6.9 mg/m^3^ and the mice exposed at 17.6 mg/m^3^ may have had similar lesion incidences because they were exposed to approximately the same inhaled “dose” of formaldehyde due to RB.

The hypothesis offered by (Kerns et al., 1983) that mice in the Battelle study inhaled about half as much formaldehyde as rats at 17.6 mg/m^3^ due to RB is logical and compelling, but there are no long-term RB data to support it at this time. Thus, although it might be considered appropriate to adjust a rodent POD to account for potential decreases in respiration (thus inferring that use of the exposure levels and corresponding results of that study may not be health protective for humans), this approach was not applied in this assessment. Overall, the lack of a long-term study to determine whether-or when rodents eventually develop tolerance to formaldehyde or any other URT irritant represents a significant data gap.

#### The potential impact of reflex bradypnea on behavioral studies

The normal physiological effects of RB can complicate the interpretation of behavioral studies in rodents. Hypothermia causes reduced peripheral nerve conduction velocity due to an apparent reduced flux of potassium and chloride ions across axon membranes. Hypothermia also causes prolonged synaptic delay time at neuromuscular junctions. A progressive decrease in body temperature results in ataxia, loss of fine motor control and reflexes, a reduction in cerebral blood flow and brain function, and eventually a loss of consciousness (OECD, 2009; Mallet, 2002). Thus, what appear to be chemically induced behavioral effects may actually be partly attributable to RB-induced hypothermia. Thus, the irritant effects were considered during evaluations of behavioral studies (see Appendix B.2.7), including a preference for studies that allowed for a recovery time of at least 2 hours after exposure before testing, given the recovery parameters discussed above.

#### The potential impact of reflex bradypnea on developmental toxicity studies

Pregnant dams are protected by RB, but their fetuses are not. Fetuses can experience developmental delays or defects due to impaired placental transfer of O_2_ (hypoxia) and CO_2_ (hypercapnia), fetal hypothermia, and malnutrition. Fetuses are more sensitive to the effects of hypothermia as compared to adults (OECD, 2009).

When dams experience RB, their fetuses may experience hypoxia due to (1) reduced maternal respiration and (2) a left shift in maternal oxyhemoglobin affinity caused by an increase in blood pH (respiratory alkalosis). Normal oxygen exchange to the fetus requires a gradient between maternal and fetal oxyhemoglobin affinities. When pregnant dams experience RB, their blood pH becomes more alkaline, resulting in a left shift in maternal oxyhemoglobin affinity. A maternal left shift results in the affinities of maternal and fetal oxyhemoglobin being indistinguishable, which impairs oxygen exchange to the fetus (hypoxia) and removal of CO_2_ (hypercapnia). Rossant and Cross (Rossant and Cross, 2001) describe hypoxia as a normal regulator of placental development in both humans and mice.

When Holzum et al. (1994^13^) exposed pregnant rats to cyfluthrin, they observed concentration-related decreases in fetal weights (see Figure C-18); Holzum et al. also observed concentration-related decreases in placental weights. Clearly, further studies on the impact of formaldehyde and other URT irritants on the placenta and fetus are needed, but the results of Holzum et al. show how RB has the potential to delay fetal growth. It should be noted that reductions in maternal feeding and metabolism during periods of RB can result in reduced fetal glucose levels. It is also important to emphasize that RB-induced developmental effects caused by fetal hypoxia, hypercapnia, hypothermia, and malnutrition are not relevant to humans.

Figure C-18 The potential impact of reflex bradypnea on fetal development

This graph shows concentration-related decreases in placental and fetal weights in pregnant dams exposed to cyfluthrin, a pyrethroid insecticide. Note that the decrements in fetal and placental weights were lessened in the 12.8 mg/m^3^ group when the dams were provided with oxygen-rich air (39% O_2_).

Source: Holzum et al. (1994). Graph generated by Jűrgen Pauluhn (Bayer Healthcare AG, Germany).

### C.2.5 Summary

Reflex bradypnea (RB) is a protective response observed in rodents exposed to formaldehyde and other upper respiratory tract irritants. The most notable signs of RB are concentration-related decreases in body temperature, respiratory rate (breaths/minute), and minute volume. Even though the effects of RB can be striking, they are not relevant to humans. It is likely that RB occurred in most, if not all, rodent inhalation toxicity studies testing high levels of formaldehyde exposure, but the extent of RB in these studies cannot be ascertained since it was not measured. In comparative studies, mice exhibit RB at a lower formaldehyde concentration than rats and had a more pronounced and more sustained RB response than rats.

Because rodents experiencing RB have reduced minute volumes, they inhale less formaldehyde and thus are expected to experience less toxicity than if they were breathing normally. Several studies demonstrate that mice and rats do not develop tolerance to formaldehyde over as much as 10 days of exposure; however, there are no long-term studies that show whether or when rodents eventually develop a tolerance to formaldehyde. This is a significant data gap. Thus, while RB is considered during study evaluation and during evidence synthesis and integration, adjustments are not applied to account for the potential impact of RB on long-term rodent health endpoints considered for use in dose-response analysis.

## C.3 GENOTOXICITY

The evaluations of genotoxic effects of formaldehyde exposure included primary sources from peer-reviewed literature and secondary sources of peer-reviewed reports by other federal agencies and non-federal institutions (see Appendix B.2.10 for details). In general, the following criteria were considered for making judgments about evidence for the genotoxic and/or mutagenic potential of formaldehyde. These include but are not limited to: (a) nature and type of tests, (b) degree of response, (c) number and performance of test strains, (d) dose/concentration levels, (e) biological significance, (f) strength of evidence (conflicting evidence in the same assay system for the same end point), and (g) evaluation of the study results across the same end points. Studies of genotoxicity in exposed humans were consistently evaluated using a structured set of criteria (see Appendix B.3.10).

The terms genotoxicity and mutagenicity differ depending on the effect seen on DNA. Genotoxicity refers to potentially harmful effects caused either directly or indirectly to the genetic material by chemical or physical agents, and these effects are not necessarily persistent and transmissible and may or may not be associated with mutagenicity. Mutagenicity refers to the induction of permanent, transmissible changes in the amount, chemical properties, or structure of the genetic material. Mutations may involve a single gene or gene segment, a block of genes, parts of chromosomes, or whole chromosomes and result in either structural and/or numeric changes. Since mutagenicity is considered a subset of genotoxic effects, the term “genotoxic effects” will be generally used throughout the rest of the document unless the assay determines specific mutations.

A variety of genotoxic effects have been demonstrated in both in vitro and in vivo test systems as a result of exposure to formaldehyde (a summary table by genotoxic endpoint is presented in Appendix C.3.7). Note that no single genotoxicity or mutagenicity test/system or study is able to detect the entire spectrum of formaldehyde-induced genotoxic events. Therefore, genotoxic endpoints are briefly discussed for cell free systems, prokaryotic organisms, nonmammalian organisms, in vitro mammalian systems, in vivo experimental animals, and humans [reviewed in (NTP, 2010; Ma and Harris, 1988; Liteplo and Meek, 2003; IARC, 1995, 2006; Conaway et al., 1996; Auerbach et al., 1977; ATSDR, 2008). In addition, the overall weight of evidence for formaldehyde-induced mutations is considered in the context of the current EPA cancer guidelines (U.S. EPA, 2005). Note that all studies from the available database have been depicted in several of the following tables, but only the studies most relevant to this discussion are briefly described in the text.

### C.3.1 Genotoxicity of Formaldehyde in Cell-Free Systems

Formaldehyde or formalin^14^ has been shown to form both hydroxymethyl DNA (hmDNA) adducts and DNA-protein crosslinks (DPX) following treatment of various cell-free systems with formaldehyde or formalin (see Table C-14). The formation of DNA-DNA crosslinks was observed in calf thymus DNA (Chaw et al., 1980) and duplex DNA (Huang et al., 1992; Huang and Hopkins, 1993). Furthermore, DNA-protein crosslinks were seen in plasmid DNA, calf thymus histones, and other acelluar systems (Lu et al., 2008; Lu, 2009; Lu et al., 2010b; Kuykendall and Bogdanffy, 1992). The formation of hmDNA adducts was observed following in vitro reaction of formalin in solution with free DNA ribonucleoside (Kennedy et al., 1996), deoxyribonucleosides and nucleotides (Mcghee and von Hippel, 1975a, b; Cheng et al., 2003; Cheng et al., 2008), calf thymus DNA (Von Hippel and Wong, 1971; Fennell, 1994; Beland et al., 1984), human placental DNA (Zhong and Hee, 2004), and isolated rat liver nuclei (Heck and Casanova, 1987; Fennell, 1994). Cheng et al. (2008) also reported that nitrosamines which form formaldehyde during their metabolism via formation of α-esters can react in vitro with deoxyribonucleosides or calf thymus DNA and form the hmDNA adducts. Studies have shown that N^6^-hydroxymethyl-deoxyadenosine (N^6^-hmdAdo) was the predominant adduct formed followed by N^2^-hydroxymethyl-deoxyguanosine (N^2^-hmdGuo) and N^4^-hydroxymethyl-deoxycytidine (N^4^-hmdCyd) when formaldehyde was reacted with calf thymus DNA (Cheng et al., 2008; Beland et al., 1984) or human placental DNA (Zhong and Hee, 2004).

Table C-14 Summary of genotoxicity of formaldehyde in cell-free systems

Test system | Dose and agent^a^ | Results^b^ | Duration; method | Reference
DNA-DNA crosslinks
Calf thymus DNA | 0.17 mM 37% HCHO | + | 40 d; RP-HPLC | Chaw et al. (1980)
Duplex DNA | 25 mM HCHO | + | 9 d; DPAGE | Huang et al. (1992)
Duplex DNA | 25 mM HCHO | + | 9 d; DPAGE | Huang and Hopkins (1993)
DNA-protein crosslinks
Lysine or Cysteine and dG | 50 mM 20% HCHO in H_2_O | + | 48 hrs; RP-HPLC/LC_MS | Lu et al. (2010a)
Histone 4 | 50 mM 20% HCHO in H_2_O | + | 10 min; LC-MS | Lu et al. (2008)
Plasmid DNA, calf thymus histones | 0.0015 mM HCHO | + | 1 hr; filter binding assay | Kuykendall and Bogdanffy (1992)
Calf thymus DNA | 0.5 mM HCHO | + | 4 hrs; ESI-MS/MS | Lu (2009)
DNA adducts
Guanosine | 2,400 mM 37% HCHO | + | 48 hrs | Kennedy et al. (1996)
Deoxyguanosine | 2,300 mM formalin^c^ | + | 20 hrs | Cheng et al. (2003)
Guanosine | 0.001 mM HCHO | + | 90 hrs | Cheng et al. (2003)
DNA nucleosides/ nucleotides | 50 mM formalin | + | 72–120 hrs | Mcghee and von Hippel (1975a)
DNA nucleosides/ nucleotides | 300 mM formalin | + | 72–120 hrs | Mcghee and von Hippel (1975a)
Calf thymus DNA | 0.001 mM formalin | + | 90 hrs | Cheng et al. (2003)
Calf thymus DNA | 0.167 mM formalin | + | 48 hrs | Beland et al. (1984)
Calf thymus DNA | 0.4 mM formalin | + | 4 hrs | Fennell (1994)
Calf thymus DNA | 200 mM formalin | + | 20 hrs | Von Hippel and Wong (1971)
Calf thymus DNA or deoxyribonucleosides | 50 mM α-acetates of NDMA; NNK and NNAL^d^ | + | 1 or 90 hrs | Cheng et al. (2008)
Human placental DNA | 3.34 mM formalin | + | 20 hrs | Zhong and Hee (2004)
Rat - Hepatic nuclei | 0.1 mM HCHO (^14^C and ^3^H) aqueous solution | + | 0.5 hr | Heck and Casanova (1987)
Rat - Hepatic nuclei | 0.4 mM ^14^C-HCHO | + | 4 hrs | Fennell (1994)

a lowest effective concentration for positive results; highest concentration tested for negative or equivocal results.

b + = positive, all experiments performed without exogenous activation.

c Formalin – all experiments with formalin contained 37% formaldehyde plus 10–15% methanol.

d these nitrosamines are precursors to formaldehyde.

Abbreviations: HCHO, formaldehyde; NDMA, N-nitrosodimethylamine; NNK, 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone; NNAL, 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol; DPAGE, denaturing polyacrylamide gel electrophoresis; HPLC, high performance liquid chromatography; LC-ESI-MS, liquid chromatography electrospray ionization mass spectrometry; LSC, liquid scintillation counting; MS, mass spectrometry; NMR, nuclear magnetic resonance; RP-HPLC, reverse phase high performance liquid chromatography; UV, ultraviolet.

### C.3.2 Genotoxicity of Formaldehyde in Prokaryotic Organisms

A number of reports describe the mutagenicity of formaldehyde in bacterial test systems (Salmonella typhimurium and Eschericia coli) using reverse and forward mutation assays as well as assays with specific E. coli strains for detecting deletions, insertions and point mutations (see Table C-15).

Formaldehyde was mutagenic in the reverse mutation assay in all of the studies with the Salmonella strains TA102 and TA104, and most of the studies with TA100 strains with and without metabolic activation and in strains TA2638 and TA2638a without metabolic activation. Mixed results were reported with TA97, TA98, and TA1537 strains, while most of the studies with the TA1535 and TA1538 strains were negative with or without metabolic activation (Wilcox et al., 1990; Sarrif et al., 1997; Rydén et al., 2000; O’Donovan and Mee, 1993; Müller et al., 1993; Marnett et al., 1985; Le Curieux et al., 1993; Jung et al., 1992; Dillon et al., 1998).

With respect to forward mutations, formaldehyde has been shown to induce these types of mutations both in S. typhimurium (Temcharoen and Thilly, 1983) as well as in E. coli strains (Temcharoen and Thilly, 1983; Bosworth et al., 1987). Temcharoen and Thilly (1983) showed that formaldehyde induced both toxicity and mutagenicity in the Salmonella strain TM677 (8-azaguanine sensitive), both with or without metabolic activation. On the other hand, (Bosworth et al., 1987) reported formaldehyde to be mutagenic in E. coli strain D494 uvrB, a more sensitive strain to base-pair substitutions. Furthermore, formaldehyde has been shown to induce diverse mutations in a forward mutation assay in E. coli strains GP120, GP120A, 7-2, and 33694, which contained a xanthine guanine phosphoribosyl transferase (gpt) reporter gene (Crosby et al., 1988). In this study, formaldehyde tested at two different concentrations (4 and 40 mM) produced point mutations (41%), deletions (18%), and insertions (41%) at low concentrations of exposure, while the high-dose exposure resulted predominantly in point mutations (92%). The point mutations at low-dose exposure were transversions at GC base pairs, while at high-dose exposure they were transition mutations at a single AT base pair in the gpt gene (Crosby et al., 1988).

Wang et al. (2007b) have also shown that formaldehyde causes dose-dependent increases in microsatellite instability in E. coli. Exposure to 2.5 mM formaldehyde caused a 2- to 24-fold induction in mutation frequencies of the complementary dinucleotide repeat microsatellites (GpT) and (ApC) compared to in untreated controls. It is possible that microsatellite instability could change the conformation of DNA to a Z-DNA structure, making the DNA not amenable for DNA repair.

Table C-15 Summary of genotoxicity of formaldehyde in prokaryotic systems

Test system | Dose^a^ (µg/ plate) | Agent^b^ | Results^c,d^ | | Comments | Reference
Test system | Dose^a^ (µg/ plate) | Agent^b^ | −S9 | +S9 | Comments | Reference
Reverse mutation
S. typhimurium TA100 | 10, 25 | 35% HCHO sol. | + | + | PP method; values visually determined from graph; (T) at 37.5 (−S9) and 50 (+S9) µg/plate | Orstavik and Hongslo (1985)
S. typhimurium TA100 | 12 | 37% HCHO with 10% methanol | (+) | (+) | PI method | Schmid et al. (1986)
S. typhimurium TA100 | 15, 7.5 | HCHO/mL | + | + | Suspension method | Sarrif et al. (1997)
S. typhimurium TA100 | 30 | 37% HCHO with 10–15% methanol | + | + | PI method; values visually determined from graph. Methanol tested ‘−ve’ up to 500 µg/plate (−S9 or +S9) in the same study. | Connor et al. (1983)
S. typhimurium TA100 | 30 | HCHO (form not specified) | (+) | ND | PP method | Takahashi et al. (1985)
S. typhimurium TA100 | 39 | 37% HCHO with 10–15% methanol | − (T) | − (T) | PI method | De Flora (1981)
S. typhimurium TA100 | 50 | 35% HCHO | + | + | PP method; dose range 6.25-50 µg/plate only provided | Dillon et al. (1998)
S. typhimurium TA100 | 75 | HCHO (form not specified) | − | + | PI method; −S9 data <2-fold compared to control | Sarrif et al. (1997)
S. typhimurium TA100 | 80 | 37% HCHO with 10% methanol | (+) | + | PP method | Schmid et al. (1986)
S. typhimurium TA100 | 90 | HCHO (form not specified) | − | ND | PP method; (T): >90 µg/plate | Marnett et al. (1985)
S. typhimurium TA100 | 100, 50 | 37% aq.sol. HCHO | +, + | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
S. typhimurium TA100 | 100 | HCHO (form not specified) | + | − | PP method; (T) ≥200 µg/plate | Sarrif et al. (1997)
S. typhimurium TA100 | 150 | 37% HCHO | + | ND | PP method; discrepancy in mutagenic data observed between author’s report and the graph from the citation (150 vs. ≈30 µg/plate) | Fiddler et al. (1984)
S. typhimurium TA100 | 333.3, 10 | 37% HCHO | − | + | PP method; (T): NR | Haworth et al. (1983)
S. typhimurium TA100 | 500, 20 | 37% HCHO in distilled water | (+) | + | PP method | Connor et al. (1985a)
S. typhimurium TA102 | 10 | HCHO/mL | + | ND | Fluctuation test; (T) at 30 µg/mL | Le Curieux et al. (1993)
S. typhimurium TA102 | 17.2 | HCHO (in water) | + | ND | PP method | Rydén et al. (2000)
S. typhimurium TA102 | 25 | HCHO (form not specified) | + | ND | PI method; (T) >100 µg/plate | Wilcox et al. (1990)
S. typhimurium TA102 | 50 | HCHO (form not specified) | (+) | (+) | PP method; values visually determined from graph | De Flora et al. (1984)
S. typhimurium TA102 | 50 | 35% HCHO | + | + | PP method; ‘+’ with rat S9 and ‘±’ with mouse S9; Authors show a dose range 6.25–50 µg/plate | Dillon et al. (1998)
S. typhimurium TA102 | 90 | HCHO (form not specified) | + | ND | PP method; (T): >90 µg/plate | Marnett et al. (1985)
S. typhimurium TA102 | 200, 100 | 37% aq.sol. HCHO | +, + | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
S. typhimurium TA102 | 200 | HCHO (in water) | + | ND | PI method; (T) at 600 mg/plate | Watanabe et al. (1996)
S. typhimurium TA102 | 5000 | HCHO (form not specified) | (+) | (+) | PI method; (+) by 1 lab and ‘−ve’ by 2 labs | Jung et al. (1992)
S. typhimurium TA102 | 5,000 | HCHO (form not specified) | (+) | (+) | PI method; reported ‘(+) by 1 lab and ‘−ve’ by 2 labs | Müller et al. (1993)
S. typhimurium TA104 | 50 | 35% HCHO | + | + | PP method; Authors show a dose range 6.25–50 µg/plate. | Dillon et al. (1998)
S. typhimurium TA104 | 90 | HCHO (form not specified) | + | ND | PP method; (T): >90 µg/plate | Marnett et al. (1985)
S. typhimurium TA1535 | 39 | formalin | − (T) | − (T) | PI method | De Flora (1981)
S. typhimurium TA1535 | 100 | 37% aq.sol. HCHO | −, − | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
S. typhimurium TA1535 | 100 | HCHO (form not specified) | − | − | PI method; (T) at 150 µg/plate | Sarrif et al. (1997)
S. typhimurium TA1535 | 100 | HCHO (form not specified) | − | − | PP method; (T) ≥200 µg/plate | Sarrif et al. (1997)
S. typhimurium TA1535 | 333.3 | 37%HCHO | − | − | PP method; (T): NR | Haworth et al. (1983)
S. typhimurium TA97 | 50 | HCHO (form not specified) | + | ND | PI method; (T) at 100 µg/plate | Sarrif et al. (1997)
S. typhimurium TA97 | 90 | HCHO (form not specified) | − | ND | PP method; (T): >90 µg/plate | Marnett et al. (1985)
S. typhimurium TA98 | 10, 25 | 35% HCHO sol. | + | + | PP method; values visually determined from graph; (T) at 37.5 (−S9) and 50 (+S9) µg/plate | Oerstavik and Hongslo (1985)
S. typhimurium TA98 | 30 | 37% HCHO with 10-15% methanol | + | + | PI method; Methanol tested up to 500 mg/plate (−S9 or +S9) was ‘−ve’. Values visually determined from graph. | Connor et al. (1983)
S. typhimurium TA98 | 30 | HCHO (form not specified) | (+) | ND | PP method | Takahashi et al. (1985)
S. typhimurium TA98 | 39 | 37% HCHO with 10–15% methanol | − (T) | − (T) | PI method | De Flora (1981)
S. typhimurium TA98 | 50, 100 | 37% aq.sol. HCHO | +, + | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
S. typhimurium TA98 | 50, 100 | HCHO (form not specified) | + | + | PP method; (T) ≥00 µg/plate | Sarrif et al. (1997)
S. typhimurium TA98 | 75 | HCHO (form not specified) | − | + | PI method; −S9 data <2-fold compared to control | Sarrif et al. (1997)
S. typhimurium TA98 | 90 | HCHO (form not specified) | − | ND | PP method; (T): >90 µg/plate | Marnett et al. (1985)
S. typhimurium TA98 | 333.3, 10 | 37% HCHO | − | (+) | PP method; (T): NR | Haworth et al. (1983)
S. typhimurium TA98 | 500 | 37% HCHO in distilled water | − (T) | (+) (T) | PP method | Connor et al. (1985b)
S. typhimurium TA1537 | 39 | 37% HCHO with 10-15% methanol | − (T) | − (T) | PI method | De Flora (1981)
S. typhimurium TA1537 | 50, 75 | HCHO (form not specified) | + | + | PI method | Sarrif et al. (1997)
S. typhimurium TA1537 | 100 | 37% aq.sol. HCHO | −, − | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
S. typhimurium TA1537 | 100 | HCHO | − | − | PP method | Sarrif et al. (1997)
S. typhimurium TA1537 | 333.3 | 37% HCHO | − | − | PP method; (T): NR | Haworth et al. (1983)
S. typhimurium TA1538 | 39 | formalin | − (T) | − (T) | PI method | De Flora (1981)
S. typhimurium TA1538 | 100 | 37% aq.sol. HCHO | −, − | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
S. typhimurium TA2638 | 500 | HCHO (in water) | + | ND | PI method; (T) at 1000 mg/plate | Watanabe et al. (1996)
S. typhimurium TA2638a | 17.2 | HCHO (in water) | + | ND | PP method | Rydén et al. (2000)
S. typhimurium UTH8413, UTH8414 | 500 | 37% HCHO with 10–15% methanol | − (T) | − (T) | PI method; Methanol tested ‘−ve’ up to 500 µg/plate with/without S9. | Connor et al. (1983)
S. typhimurium UTH8413, UTH8414 | 500 | 37% HCHO in distilled water | − (T) | − (T) | PP method | Connor et al. (1985b)
E. coli WP2, WP2uvrA, H/R30R, Hs30R (uvrA) | 420 | HCHO (form not specified) | + | ND | RM assay | Takahashi et al. (1985)
E. coli NG30 (recA) | 63 | HCHO (form not specified) | − | ND | RM assay; values visually determined from graph | Takahashi et al. (1985)
E. coli O16 (polA) | 52.5 | HCHO (form not specified) | − | ND | RM assay; values visually determined from graph | Takahashi et al. (1985)
E. coli K12 (AB1886)/(uvrA); K12 (AB2480)/(recA /uvrA) | 150 | HCHO (form not specified) | − | ND | RM assay | Graves et al. (1994)
E. coli K12 (AB1157)(WT) | 1,875 | HCHO (form not specified) | + | ND | RM assay | Graves et al. (1994)
E. coli WP2 (pkM101) | 200 | HCHO (form not specified) | − (T) | ND | PI method | Wilcox et al. (1990)
E. coli WP2 (pkM101) | 200, 100 | 37% aq.sol. HCHO | −, + | ND | Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
E. coli WP2 (pkM101) | 700 | HCHO (in water) | + | ND | PI method | Watanabe et al. (1996)
E. coli WP2 uvrA (pkM101) | 150 | HCHO (form not specified) | + | ND | PI method; doseresponse from 10–300 µg/plate | Wilcox et al. (1990)
E. coli WP2 uvrA (pkM101) | 200, 50 | 37% aq.sol. HCHO (form not specified) | +, + | ND | Results by Results by PI & PP methods, respectively | O’Donovan and Mee (1993)
E. coli WP2 uvrA (pkM101) | 400 | HCHO (in water) | + | ND | PI method | Watanabe et al. (1996)
E. coli (Lac+ reversion) WP3104P | 10 | HCHO (form not specified) | (+) | ND | RM assay | Ohta et al. (1999)
E. coli (Lac+ reversion) WP3101P, WP3102P, WP3103P, WP3105P, WP3106P | 30 | HCHO (form not specified) | − | ND | RM assay | Ohta et al. (1999)
Forward mutation
S. typhimurium TM677 | 0.167, 0.33 mM | 37% HCHO with 10–15% methanol | + | + | PP method | Temcharoen and Thilly (1983)
E. coli D494uvrB (pGW1700) | 6.0 µg/mL | HCHO (form not specified) | + | ND | Ampicillin FM assay | Bosworth et al. (1987)
Deletions, Insertions and Point mutations
E. coli GP120, GP120A, 7-2, 33694 | 4 mM | HCHO (form not specified) | + | ND | gpt FM assay | Crosby et al. (1988)
Microsatellite Instability
E. coli JM109 | 2.5 mM | HCHO (form not specified) | + | ND | Mutation frequency analysis and sequencing. | Wang et al. (2007b)

a lowest effective dose for positive results; highest ineffective dose tested for negative or equivocal results.

b single value indicates identical dose/concentration effective for both without (−S9) or with (+S9) metabolic activation; for −S9 assay data showing two signs (+ or −) separated by a comma indicate respectively, use of PI and PP methods.

c + = positive; − = negative; (+) = weak positive; ND = test was not done; (T), toxic.

Abreviations: HCHO, formaldehyde; PI, plate incorporation (or standard plate); PP, pre-incubation plate; FM, forward mutation; RM, reverse mutation; gpt, xanthine guanine phosphoribosyl transferase.

### C.3.3 Genotoxicity of Formaldehyde in Nonmammalian Systems

Formaldehyde (commercial grade) or formalin (mostly containing 37% formaldehyde and 10–15% methanol) has been tested in several nonmammalian systems including yeast, molds, plants, insects, and nematodes. As summarized in Table C-16, formaldehyde has been shown to cause gene conversion, strand breaks, crosslinks, homozygosis and related damage in yeasts (Saccharomyces cerevisiae); forward and reverse mutations in molds (Neurospora crassa); micronuclei formation in spiderworts (Tradescantia pallida); DNA damage and mutations in several plants; genetic cross-over or recombination, sex-linked recessive lethal mutations, dominant lethal mutations, heritable translocations, and gene mutations in insects (Drosophila melanogaster); and recessive lethal mutations in nematodes (Caenorhabditis elegans). Formaldehyde failed to show micronuclei formation in newt larvae (Pleurodeles waltl) (reviewed in reviewed in (NTP, 2010; IARC, 2006, 2012)). DNA protein crosslinks were observed in Saccaromyces cerevisiae and E. coli (Wilkins and Macleod, 1976; Magaña-Schwencke and Ekert, 1978; Magaña-Schwencke and Moustacchi, 1980).

Some of the nonmammalian studies compared the effects of formaldehyde in wild type and DNA repair-deficient organisms. For example, (Magaña-Schwencke et al., 1978) showed that excision repair-deficient Saccharomyces cerevisiae strains are more susceptible to formaldehyde-induced lethal effects and have reduced capacity to form single strand breaks (SSBs) compared with repair-proficient strains, suggesting that the repair process possibly involves SSB formation. Also, formaldehyde is more mutagenic in repair-deficient Neurospora crassa compared to the corresponding repair-proficient strains (de Serres and Brockman, 1999).

Table C-16 Summary of genotoxicity studies for formaldehyde in nonmammalian organisms

Test system | Concentration^a,b^ | Results^c^ | Comments^d^ | Reference
DNA damage
Various plant and fungal species^e^ | 1233 mM 3.7% HCHO (at pH 3.0 and 7.0) | + | 1.5 hrs, PCR/GE, | Douglas and Rogers (1998)
DNA protein crosslinks
Saccharomyces (S.) cerevisiae | 17 mM HCHO (form not specified) | + | 0.25 hrs, DNA extractability; (T) 90 & 60% survival at 33 & 66 mM HCHO with 42 & 95% DNA damage, respectively | Magaña-Schwencke and Ekert (1978)
S. cerevisiae | 33 mM HCHO (form not specified) | + | 0.25 hrs, DNA extractability; (T) 90 & 60% survival at 33 & 66 mM HCHO with 42 & 95% DNA damage, respectively | Magaña-Schwencke and Moustacchi (1980)
E. coli | 130 mM HCHO (form not specified) | + | 10 min; alkaline sucrose gradient centrifugation | Wilkins and Macleod (1976)
DNA repair inhibition
S. cerevisiae | 66 mM HCHO (form not specified) | + | 0.25 hrs, ASG; (T) 90 & 60% survival at 33 & 66 mM HCHO with 42 & 95% DNA damage, respectively | Magaña-Schwencke and Ekert (1978)
Dominant lethal mutation
Drosophila (D.) melanogaster | 60 mM 36% HCHO in water | + | larval feeding method, frequency of hatchability | Auerbach and Moser (1953a, 1953b)
D. melanogaster | 43 mM HCHO (form not specified) | + | Exposure duration NR, frequency of dominant lethal mutations | Srám (1970)
Forward mutation
Neurospora (N.) crassa heterokaryon H-59 strain | 3 mM formalin | + | 3 hrs, frequency of ad-3 mutations | de Serres et al. (1988); de Serres and Brockman (1999)
N. crassa heterokaryon H-12 strain | 8 mM formalin | (+) | 3 hrs, frequency of ad-3 mutations | de Serres et al. (1988); de Serres and Brockman (1999)
Gene conversion
S. cerevisiae strain D4 | 18 mM 30% HCHO solution | + | 0.5 hr, frequency of recombinants | Chanet et al. (1975)
Genetic crossing over or recombination
D. melanogaster | 14 mM HCHO (form not specified) | + | larval feeding method | Alderson (1967)
D. melanogaster | 42 mM HCHO (form not specified) | + | duration of exposure NR, frequency of recombinant | Sobels and van Steenis (1957)
D. melanogaster | 83 mM HCHO (form not specified) | + | duration of exposure NR, frequency of cross overs | Ratnayake (1970)
Heritable translocation
D. melanogaster | 14 mM HCHO (form not specified) | + | 2 hrs, frequency of recombinants | Khan (1967)
D. melanogaster | 83 mM HCHO (form not specified) | + | duration of exposure NR, frequency of translocations | Ratnayake (1970)
Homozygosis by mitotic recombination or gene conversion
Saccharomyces cerevisiae | 0.62 mM formalin | + | 16 hrs, frequency of resistant colonies | Zimmermann and Mohr (1992)
Micronucleus
Pleurodeles waltl | 0.17 mM HCHO (form not specified) | − | 168 hrs, Masson’s haemalum staining | Siboulet et al. (1984)
Pleurodeles waltl larva | 0.33 mM HCHO (form not specified) | − | 12 hrs, Masson’s haemalum staining | Le Curieux et al. (1993)
Tradescantia pallida | 8 mM HCHO (form not specified) | + | 6 hrs, acetocarmine staining | Batalha et al. (1999)
Mutation
Plants (others) | NR | + | NR | Auerbach et al. (1977)
Reverse lethal mutation
Caenorhabditis elegans | 23 mM HCHO from PFA | + | 4 hrs, frequency of mutations | Johnsen and Baillie (1988)
Reverse mutation
Neurospora crassa | 10 mM HCHO (form not specified) | + | 4 hrs, frequency of mutations | Jensen et al. (1951)
Neurospora crassa | 10 mM formalin | − | 3 hrs, frequency of mutations | Kölmark and Westergaard (1953)
Neurospora crassa | 24 mM HCHO (form not specified) | − | 0.5 hrs, frequency of mutations | Dickey et al. (1949)
Sex-linked lethal mutation
D. melanogaster | 8 mM formalin | + | larval feeding method, frequency of sex linked lethals | Stumm-Tegethoff (1969)
D. melanogaster | 14 mM HCHO (form not specified) | + | larval feeding method | Alderson (1967)
D. melanogaster | 14 mM HCHO (form not specified) | + | 2 hrs, frequency of progeny | Khan (1967)
D. melanogaster | 33 mM formalin | + | duration of exposure NR, frequency of eclosions | Kaplan (1948)
D. melanogaster | 42 mM HCHO (form not specified) | + | Exposure duration NR, frequency of sex-linked lethals | Sobels and van Steenis (1957)
D. melanogaster | 60 mM 36% HCHO in water | + | larval feeding method, frequency of sex linked lethals | Auerbach and Moser (1953b); Auerbach and Moser (1953a)
D. melanogaster | 67 mM HCHO (form not specified) | (+) | larval feeding method, frequency of sex linked lethals | Ratnayake (1968)
D. melanogaster | 73 mM HCHO (form not specified) | + | duration of exposure NR, frequency of sex-linked lethals | Ratnayake (1970)
Single strand breaks
S. cerevisiae | 33 mM HCHO (form not specified) | + | 0.25 hrs, ASG; (T) 90 & 60% survival at 33 & 66 mM HCHO with 42 & 95% DNA damage, respectively | Magaña-Schwencke et al. (1978)

a indicates lowest effective concentration for positive results; highest concentration tested for negative or equivocal results.

b indicates that the multiple dose/concentration values reported correspond to order of the indicated test result(s) (e.g., without activation; with activation). Identical doses/concentrations for multiple test results are indicated by a single value.

c indicates + = positive; − = negative; (+) = weak positive.

d indicates the duration of exposure and the assay used to assess the endpoint, dose-response and toxicity (T) if any.

e indicates that authors tested the following species: Agaricus bisporus, Glycine max, Lycopersicon esculentum, Pinus resinosa, Pisum sativum, Populus x euramericana, Vicia faba, and Zea mays.

Abbreviations: ad-3, adenine-3 locus; ASG, alkaline sucrose gradient; HCHO, formaldehyde; NR, not reported; PCR/GE, polymerase chain reaction/gel electrophoresis; PFA, paraformaldehyde.

### C.3.4 Genotoxicity of Formaldehyde in in Vitro Mammalian Cells

Formaldehyde has been tested for its genotoxic potential in several mammalian cell culture systems originating from rodents (mice, rats, hamsters) and humans, mostly without metabolic activation. In a majority of these systems, formaldehyde tested positive for: DNA reactivity including DNA adducts, DPXs, and SSBs; cytogenetic changes such as sister chromatid exchanges (SCEs), chromosomal aberrations (CAs), and micronuclei (MN); cell transformation and mutation induction; and other genotoxic endpoints such as unscheduled DNA synthesis (UDS) and DNA repair inhibition (summarized in Table C-17).

#### DNA Reactivity and Damage

##### DNA adducts

Formaldehyde has been shown to form hmDNA adducts in CHO cells (Beland et al., 1984) and rat and human nasal epithelial cells (Zhong and Que Hee, 2004) as shown in Table C-17. Beland et al. (1984) first reported hmDNA adducts in CHO cells incubated with 1 mM of radiolabeled formaldehyde. After a 2-hour incubation, small amounts of N^6^-hmdA were detected with concomitant metabolic incorporation of formaldehyde (i.e., into DNA bases). Zhong and Que Hee (2004) reported three types of hmDNA adducts in human nasal epithelial cells exposed to varying concentrations of formalin (10–500 μg/mL). In this study, the hmDNA adduct levels were in the order of N^6^-hmdA > N^2^-hmdG > N^4^-hmdC. In HeLa cells exposed to [^13^CD_2_]-formaldehyde, (Lu et al., 2012a) detected both exogenous (^13^C-labeled) and endogenous (unlabeled) N^2^-hmdG adducts; however, this study detected endogenous but not exogenous N^6^-hmdA adducts.

##### DNA-protein crosslinks

As summarized in Table C-17, DNA protein crosslinks have been reported in several mammalian cell lines (primary and transformed) from rodents (mice, rats, hamsters) and humans (reviewed in (IARC, 1995, 2006; Conaway et al., 1996).

The lowest effective concentration of formaldehyde or formalin causing DPX formation varied between different cell lines (see Table C-17). Among the animal cell lines, DPX formation was observed at the in vitro concentrations of 0.125–0.25 mM in CHO cells and 0.01–0.2 mM in V79 cells. Several human cell lines (either primary cells or developed cells lines), including epithelial, fibroblasts, buccallymphoblastoid, lymphoma, and peripheral blood lymphocytes, among others, that were exposed to formaldehyde also formed DPXs (Li et al., 2004; Emri et al., 2004; Craft et al., 1987; Costa et al., 1997). Selected studies have been briefly described below, although all available and relevant studies are included in Table C-17).

Craft et al. (1987) analyzed DPXs in TK6 human lymphoblastoid cells immediately after a 2-hour exposure (zero time) to 0–600 μM formaldehyde with a significant nonlinear increase in DPXs above 50 μM, which correlated with the onset of cytotoxicity. DPXs were completely repaired within 24 hours after exposure.

DPXs were also detected in Epstein-Barr Virus (EBV)-human Burkitt’s lymphoma cells exposed to paraformaldehyde (which depolymerizes to release formaldehyde) at doses that were cytotoxic (>0.003%) (Costa et al., 1997). Grafström et al. (1986) reported that the number of DPXs induced by 100 μM formaldehyde in vitro in human bronchial epithelial cells and fibroblasts was similar; although, DPX levels were several-fold higher than SSBs in the epithelial cells. In a different study, the same authors (Grafstrom et al., 1984) noted that formaldehyde exposure resulted in the formation of DPXs at similar levels in bronchial epithelial cells and in DNA excision repair-deficient xeroderma pigmentosum (XP) skin fibroblasts, and their removal rate was similar with a half-life of 2–3 hours, suggesting that the DPXs are repaired independently of excision repair. Further, formaldehyde was only moderately cytotoxic to normal bronchial epithelial cells and fibroblasts at concentrations that induced substantial DNA damage. Repair of the formaldehyde-induced DNA SSBs and DPXs appeared to be inhibited by the continued presence of formaldehyde in the culture medium (Grafstrom et al., 1984).

A linear increase in DPX levels was observed in primary human skin fibroblasts and keratinocytes from 25–100 μM formaldehyde, as indicated by the ability of formaldehyde to reduce DNA migration in the comet assay after methylmethane sulfonate (MMS) pretreatment (Emri et al., 2004). Similar findings were also reported for primary human peripheral blood lymphocytes (PBLs) and HeLa cells (LICM, 2006). Peak response for SSBs was seen at 10 μM in both cells, with higher concentrations resulting in crosslink formation (LICM, 2006). DPX formation was also observed in a whole blood culture after exposure to 25 µM, as indicated by the effect of formaldehyde on DNA migration in the comet assay after γ–radiation (Schmid and Speit, 2007). The repair of DPXs was complete 8 hours after an exposure to 100 µM formaldehyde, while DPXs formed at >200 mM was repaired within 24 hours.

Formaldehyde-induced DPXs are removed either through spontaneous hydrolysis or active repair processes (Quievryn and Zhitkovich, 2000). Inhibition of specific proteosomes (protein complexes involved in degrading unwanted or damaged proteins) in xeroderma pigmentosum (XP)-A cells inhibited DPX repair, thereby supporting the role of enzymatic degradation (Quievryn and Zhitkovich, 2000). The average half-life of formaldehyde-induced DPXs in human epithelial cell lines was 12.5 hours (range 11.6 to 13 hours) (Quievryn and Zhitkovich, 2000), 18 hours in HeLa cells (LICM, 2006), and 24 hours in human lymphoblasts (Craft et al., 1987). This difference was primarily due to slower active repair of DPXs, with a t^1/2^ of 66.6 hours for human lymphocytes compared to other human cell lines (Quievryn and Zhitkovich, 2000).

Speit et al. (2000) hypothesized that single peptides or small peptide chains cross-linked to DNA are critical to formaldehyde-induced mutation. However, these authors did not find significant differences in the induction and repair of DPXs in a normal human cell line (MRC4CV1), nucleotide excision repair (NER)-deficient xeroderma pigmentosum (XP) fibroblast cell line, and a Fanconi anemia (FA) cell line exposed to 125–500 μM formaldehyde for 2 hours. In contrast, these cells showed increased susceptibility to formaldehyde-induced MN formation. It is suggested that the NER pathway affects cytogenetic makers of genotoxicity rather than the cross-link repair (Speit et al., 2000).

##### DNA Single Strand Breaks (SSBs)

Formaldehyde has been shown to induce SSBs in a number of mammalian cell systems in vitro (see Table C-17). Certain cell lines seem to be more sensitive for SSB formation than others. For example, formaldehyde induced SSBs at concentrations ranging from 0.005–0.8 mM in human primary cells including lung/bronchial epithelial cells (Saladino et al., 1985; Grafstrom et al., 1984; Grafstrom, 1990; Fornace et al., 1982), skin fibroblasts (Snyder and van Houten, 1986; Grafstrom et al., 1984), lymphocytes (LICM, 2006), and in human cell lines A549 (Vock et al., 1999) and HeLa (LICM, 2006) cells, and rat hepatocytes (Demkowicz-Dobrzanski and Castonguay, 1992). In many of these studies SSB induction was dose-dependent. However, formaldehyde did not induce SSBs in human foreskin fibroblasts (Snyder and van Houten, 1986), human skin keratinocytes exposed for 20 hours (Emri et al., 2004), mouse leukemia cells (Ross and Shipley, 1980; Ross et al., 1981), hamster CHO cells (Marinari et al., 1984), and V79 cells (Speit et al., 2007b).

Formaldehyde induces more DPXs than SSBs in normal human bronchial epithelial cells (Saladino et al., 1985; Grafstrom, 1990). Grafstrom et al. (1984) examined the kinetics of DNA repair in nucleotide excision repair (NER)-proficient human bronchial epithelial cells and fibroblasts and NER-deficient fibroblasts from XP patients by the alkaline elution technique. They reported comparable levels of DPX in all cell lines, suggesting non-involvement of NER in DPX removal. However, SSB levels are higher than DPX levels in XP cells compared to normal fibroblasts, although both these DNA lesions are repaired at comparable rates, suggesting an additional indirect mechanism of SSB formation possibly involving a different repair pathway. SSBs in HeLa cells induced by 10 μM formaldehyde were repaired by 90 minutes after cells were washed to remove formaldehyde (LICM, 2006).

#### Cytogenetic markers of genotoxicity

Clastogenic effects, including increased MN, CAs, and SCEs, have been reported in a variety of in vitro systems as shown in Table C-17.

##### Micronucleus (MN) formation

Studies have shown MN formation in V79 lung epithelial cell lines (Speit et al., 2007b; Merk and Speit, 1998), in human fibroblasts with varying DNA repair backgrounds (Speit et al., 2000), and in whole blood cultures (Schmid and Speit, 2007). Speit et al. (2000) reported a higher frequency of MN formation in xeroderma pigmentosum (XP) and Fanconi anemia (FA) cell lines compared to normal human cell lines suggesting the importance of NER and crosslink repair following formaldehyde exposure. In V79 cells, Speit et al. (2007b) observed that MN frequency increased with repeated formaldehyde treatments compared to a single treatment; however, such an increase was not observed if the treatment interval was increased to 24 hours. An increase in micronucleus frequency was observed in mouse erythropoietic cells (Ji et al., 2014), human A549 lung epithelial cells (Speit et al., 2011a), human lymphoblasts (Ren et al., 2013), and human whole blood cultures (Speit et al., 2011a).

Schmid and Speit (2007) observed a statistically significant increase in MN formation at or above a formaldehyde concentration of 300 µM in human whole blood cultures treated with formaldehyde 24 hours after the start of the culture and cytochalasin B (CytB) added 20 hours later (44 hours after the start of the culture). This prompted the conclusion that the level of DPX formation from formaldehyde exposure would need to be high for MN formation and the cells must be exposed after the first mitosis (which is 24 hours). In examining MN formation more closely with Fluorescence In Situ Hybridization (FISH), Schmid and Speit (2007) found that 81 percent of the time, formaldehyde was inducing a micronuclei that was centromere negative indicating the effect to be clastogenic rather than aneugenic (a centromere contained micronuclei).

##### Sister chromatid exchanges (SCEs)

Sister chromatid exchanges occur as a result of errors in the replication process, where an exchange in the chromatids between sister chromatids occurs during the anaphase. DPX are likely to cause replication block and might stimulate SCEs in cells. Therefore, evaluation of SCEs is important in assessing the genotoxicity of formaldehyde.

Formaldehyde has been shown to induce SCEs in most of the in vitro studies, both in rodent and human cells. The available studies are summarized in Table C-17. Different cell types responded differently to various concentrations of formaldehyde, particularly at low doses. For example, the lowest effective concentration (LEC) of formaldehyde in Chinese hamster embryo cells was 0.01 mM, for CHO cells it was 0.03 mM, and V79 cells responded at a concentration of 0.06 mM, while human lymphocytes required slightly higher concentrations (0.125 mM) to show any effect. Neuss and Speit (2008) observed a significant dose-dependent increase in SCE formation in V79 cells and A549 cells following a range of formaldehyde concentrations with 0.1 mM being the LEC when BrdU was added immediately after formaldehyde exposure. However, when BrdU addition was delayed by 4 hours the LEC increased to 0.2 mM suggesting DNA repair. In co-cultivation experiments, the authors first treated A549 cells for 1 hour with 0.05 mM formaldehyde and then co-cultured them with V79 cells with or witout changing the culture medium, SCEs were observed in A549 cells in both situations, but in the co-cultured V79 cells, SCEs were observed only when the medium was not changed, suggesting residual availability of formaldehyde in the medium to induce SCEs in V79 cells and that formaldehyde which entered the A549 cells is either utilized or inactivated. Miyachi and Tsutsui (2005) measured the induction of SCEs in Syrian hamster embryo (SHE) cells at an LEC of 0.01 mM within an hour of formaldehyde exposure. Schmid and Speit (2007) observed that SCEs were induced by 200 µM in lymphocytes from human whole blood cultures, an effect apparently associated with cytotoxicity as indicated by a concomitant reduction in the proliferative index.

##### Chromosomal aberrations (CAs)

Several studies have demonstrated formaldehyde-induced CAs in a variety of mammalian cells, such as CHO cells (Natarajan et al., 1983; Lorenti Garcia et al., 2009), Chinese hamster lung fibroblasts (Ishidate et al., 1981), Syrian hamster embryo (SHE) cells (Hikiba et al., 2005; Hagiwara et al., 2006), mouse lymphoma cells (Speit and Merk, 2002), human PBLs (Schmid et al., 1986; Dresp and Bauchinger, 1988), and human fibroblasts (Levy et al., 1983).

Hikiba et al. (2005) used SHE cells to measure the induction of CAs following exposure to a series of formaldehyde concentrations (0, 33, 66, and 99 μM) for 24 hours and observed the percentages of aberrant metaphases to be 0, 6, 6, and 71, respectively. The aberrations were predominantly chromosome gaps and chromosomal breaks and exchanges. The relative colony-forming efficiency remained high (at least 85%). Dose-dependent increases in chromosomal aberrations were observed when CHO cells were exposed to 0.15 mM of commercial formaldehyde (Lorenti Garcia et al., 2009). Chinese hamster lung fibroblasts, when exposed to 0.6 mM formalin induced chromosomal aberration within 24 hour of exposure (Ishidate et al., 1981). Note that formalin was used in this study as a source of formaldehyde.

Dresp and Bauchinger (1988) exposed human lymphocytes to various concentrations of formaldehyde. A dose-dependent increase in chromosomal aberrations was observed. Schmid et al. (1986) used the same cell lines and exposed them to 0.25 and 0.5 mM formaldhyde containing 10% methanol. Both chromatid breaks and gaps were observed. It should be recognized that the in vitro studies used different forms of formaldehyde, including commercial grade formaldehyde, paraformaldehyce, formalin (formaldehyde containing 10–15% methanol) or methanol-free formaldehyde.

##### Mutations and cell transformation

Mutations may occur as a result of the misrepair of formaldehyde-induced DNA damage (DPXs, DNA adducts, SSBs, or clastogenic effects) or as a result of replication errors during mitogenesis. The in vitro evidence for formaldehyde-induced mutations, as discussed below, is strengthened by the correlation between these genotoxic and clastogenic events of formaldehyde and the induction of mutations in other test systems. Numerous studies have demonstrated formaldehyde-induced DNA mutations under a variety of experimental conditions (reviewed in (NTP, 2010; Ma and Harris, 1988; Liteplo and Meek, 2003; IARC, 1995, 2006, 2012; Conaway et al., 1996; Auerbach et al., 1977)).

###### Deletion and point mutations

Several studies demonstrated deletion mutations in cultured mouse lymphoma cells (Speit and Merk, 2002; Mackerer et al., 1996), CHO cells and V79 lung epithelial cells at the hypoxanthine phosphoribosyl transferase (hprt) locus (Merk and Speit, 1998, 1999; Graves et al., 1996; Grafström et al., 1993) as well as in human TK6 lymphoblast cells (Goldmacher and Thilly, 1983; Crosby et al., 1988; Craft et al., 1987) as shown in Table C-17.

Craft et al. (1987) measured the induction of mutations in the thymidine kinase (tk) locus or at the ouabain resistance (Oua^r^) locus in TK6 human lymphoblastoid cells. The mutagenesis at tk locus can result from base-pair substitutions, small and large deletions, and chromosome exchange events, while mutations at the Oua^r^ locus require specific base-pair substitutions. Lymphoblostoid cells were exposed to single (0, 15, 30, 50, 125, or 150 µM for 2 hours) or multiple treatments, that is, 3, 5, or 10 treatments of 50, 30, or 15 µM, respectively, or 4 treatments of 150 µM for 2 hours (treatments were spaced 2–4 days apart) with formaldehyde and mutations analyzed. The authors observed a nonlinear increase in tk mutagenesis with single treatment of formaldehyde with an increasing slope at >125 µM. Although multiple treatments caused an increase in tk mutagenesis, their combined effect was less than the single treatment of equivalent C × t (150 µM × 2 hours). No mutations were observed at the Oua^r^ locus in lymphoblasts that received four treatments of 150 µM for 2 hours. Tk mutagenesis followed a similar exposure-response curve as DPX formation in this study (Craft et al., 1987).

Using the same cell system, (Crosby et al., 1988) showed that repetitive treatments of 150 μM formaldehyde induced mutants at the X-linked hypoxanthine-guanine phosphoribosyl transferase (HPRT) locus. Of these mutants, 14/30 of them contained partial or complete deletions with most of the partial deletions showing unique deletion patterns, while only a third (5/15) of spontaneous mutants had partial or complete deletions, indicating that formaldehyde can induce large losses of DNA in human lymphoblast cells. This work was followed up by (Liber et al., 1989), who showed that HPRT mRNA from human lymphoblast mutants (16 formaldehyde-induced and 10 spontaneous, both not showing deletions) contained a preferential AT to CG transversion at a specific site (Liber et al., 1989).

Formaldehyde has been shown to induce hprt mutations in CHO cells involving single-base pair transversions mostly occurring at AT sequences (Graves et al., 1996). Formaldehyde also induced forward mutations in mouse lymphoma L5178Y tk± cells both in the absence and presence of rat liver S9 (higher concentrations were required for an effect with S9). Both toxicity and mutagenicity were abolished when formaldehyde dehydrogenase (FADH) was incorporated in the exposure medium (Blackburn et al., 1991), suggesting detoxification of formaldehyde.

A study by Merk and Speit (Merk and Speit, 1998) indicated that formaldehyde-induced DPXs did not result in direct gene mutations in the hprt locus of V79 Chinese hamster cells, suggesting that formaldehyde was not mutagenic. However, the hprt mutation assay may be insensitive to deletion mutations (Merk and Speit, 1998) because the hprt locus in the V79 cell line is primarily sensitive to point mutations. Additionally, one study showed the formation of deletion mutations by formaldehyde at the same locus in human lymphoblasts (Crosby et al., 1988).

In the mouse lymphoma assay (L5178Y cells), Speit and Merk (Speit and Merk, 2002) demonstrated that a 2-hour exposure to formaldehyde was mutagenic in a concentration-dependent manner. Mutation was mainly attributed to a strong increase in small colony mutants suggestive of CAs. Recombination or deletion of DNA from the tk locus was primarily responsible for the loss of heterogeneity, thereby leading to the observed mutant phenotype. This mutagenic finding in the L5178Y cell mouse lymphoma system, which is likely to occur by a clastogenic mechanism rather than by point mutations (Speit and Merk, 2002), is consistent with that of (Craft et al., 1987), who demonstrated formaldehyde mutagenicity at the tk locus of TK6 cells, and also with the findings of (Grafstrom et al., 1984), who demonstrated increased SSB formation in formaldehyde-exposed cell lines.

###### Transformation

Formaldehyde has also been shown to induce cell transformation in mouse embryo fibroblasts (Ragan and Boreiko, 1981; Frazelle et al., 1983; Boreiko and Ragan, 1983) and hamster kidney cells (Plesner and Hansen, 1983) as shown in Table C-17. In mouse embryonic C3H/10T^1/2^ cells, a single exposure to formaldehyde (0.003–0.083 mM) for 24 hours did not induce transformation; however, when formaldehyde treatment was followed by continuous treatment with 0.1 µg/mL with the tumor promoter 12-O-tetradecanoyl phorbol-13-acetate (TPA), a dose-dependent increase in transformation was observed at low concentrations of 0.003 mM (Boreiko and Ragan, 1983) or 0.017 mM (Ragan and Boreiko, 1981) formaldehyde. Ragan and Boreiko (1981) have also shown that treatment of mouse embryo fibroblasts with varying doses of formic acid (≈2 to 22 mM) or methanol (≈0.11 to 1.1 M) did not induce transformation either alone or following TPA promotion in mouse embryo fibroblasts. The authors concluded that since commercial formalin contains 10% methanol, and use of 105 times higher methanol concentrations (≈2.2 M) in this experiment ruled out the background interference of methanol (precursor to formaldehyde) or formic acid (a metabolic product of formaldehyde) with formaldehyde-induced cell transformation. In a different study using the same cells, the ability of formaldehyde to act as a tumor promoter was tested with repeated applications of formaldehyde following initiation with N-methyl-N’-nitro-N-nitrosoguanidine (MNNG) by (Frazelle et al., 1983) who observed a weak tumor promoting activity of formaldehyde. Another study with a 3-hour exposure to formaldehyde (0.003 to 3.33 mM) with metabolic activation using S9 mix in baby hamster kidney (BHK) cells induced dose-dependent increase in transformation (Plesner and Hansen, 1983).

###### p53 mutation and cell death

Four cell lines derived from formaldehyde induced rat nasal squamous cell carcinomas (SCCs) from a previous study (Recio et al., 1992) were analyzed by Bermudez et al. (1994) for p53 mutations as shown in Table C-17. These cell lines were aneuploid overexpressing transforming growth factor-α and epidermal growth factor, expression of which is a common feature of SCCs and is frequently found in human tumors. Two of these cell lines contained wild type DNA sequences while the two others possessed mutated p53 gene sequences, being point mutations, specifically having transversions at codons 132 (TTCàTTA) and 271 (CGTàCAT) of the p53 gene. To understand the mechanism of transformed cell lines converting to the tumor phenotype, the authors injected either the wild type cells or cells with mutant p53 sequences into nude mice. They observed that only cell lines expressing the p53 mutation were tumorigenic, suggesting involvement of specific p53 mutations in the tumorigenicity of formaldehyde. Wong et al. (2012) examined signal transduction pathways in response to formaldehyde exposure. The authors studied p53 phosphorylation in human lung epithelial (H460 cells) and fibroblast cells exposed to formaldehyde and compared the role of different protein kinases using specific inhibitors for ATR, ATM, and DNA-dependent protein kinases, measuring Ser15p53 and thr68-CHK1 phosphorylation, p53 accumulation, and induction of p21. At low doses, formaldehyde-induced DNA-protein crosslinks caused ATR-mediated activation of p53 in human lung fibroblasts and epithelial cells. The S-phase of the cell cycle seems to be specifically sensitive for this effect without the involvement of topoisomerase binding protein 1 (topBP1). For other pathways, such as BER and NER, mismatch repairs were not affected by p53 activation, suggesting that non-DPX adducts, including DNA-peptide and hmDNa adducts, play a minor role in formaldehyde-induced p53 activation.

##### Other genotoxic endpoints

As summarized in Table C-17, in vitro formaldehyde exposure induces other genotoxic and related effects in mammalian cells such as unscheduled DNA synthesis (UDS) and DNA repair inhibition.

###### Unscheduled DNA synthesis

UDS, which represents DNA repair activity following excision of DNA damage, has been reported in rat hepatocytes (Williams et al., 1989b) and SHE cells (Hamaguchi and Tsutui, 2000) exposed to formaldehyde. UDS was also observed in HeLa cells (Martin et al., 1978), but not in human bronchial epithelial cells (Doolittle et al., 1985) upon formaldehyde exposure. These studies suggest that formaldehyde-induced DNA damage was followed by DNA repair.

###### DNA repair inhibition

Formaldehyde can inhibit DNA repair and induce cell transformation (Speit et al., 2000; Grafstrom et al., 1984; Emri et al., 2004; Boreiko and Ragan, 1983) as shown in Table C-17. Studies have shown that formaldehyde causes DNA repair inhibition at a concentration range of 0.125 mM to 10 mM in human bronchial epithelial cells (Grafstrom et al., 1984) and skin fibroblasts or keratinocytes (Emri et al., 2004), DNA repair proficient or deficient cell lines (e.g., XP), or cell lines hypersensitive to DNA-DNA crosslinks (e.g., FA) (Speit et al., 2000). In a study using human keratinocytes and fibroblasts, Emri et al. (2004) tested the formation of DNA SSBs induced by ultraviolet (UV) irradiation by UVB or UVC with or without prior treatment with 10 μM formaldehyde. The authors reported that SSB induced by UV irradiation alone were repaired within 3–6 hours of exposure, while cells with UV irradiation followed by formaldehyde exposure had higher SSBs at the same time points due to increased chromosomal damage, suggesting that formaldehyde exposure altered the repair kinetics in these cells.

###### Aneuploidy

Studies on aneuploidy in various in vitro cell systems have provided mixed results as shown in Table C-17. For example, an increase in aneuploidy was observed in hamster CHO cells (Kumari et al., 2012) and human erythropoietic stem cells (Ji et al., 2014). However, no increase in aneuploidy cells were observed in hamster V79 lung epithelial cells (Speit et al., 2011a; Kuehner et al., 2012) or in human myeloid progenitor cells (Kuehner et al., 2012).

Table C-17 Summary of in vitro genotoxicity studies of formaldehyde in mammalian cells

Test system | Dose/ Concentration^a^ | Results^b^ | | Comments (duration; endpoint method; toxicity) | Reference
Test system | Dose/ Concentration^a^ | -S9 | +S9 | Comments (duration; endpoint method; toxicity) | Reference
p53 Mutations
Rat; Nasal tumor cell lines | NA | + | ND | cell lines derived from nasal tumors of rats from 2-year tumor study; rats exposed to 18.5 mg/m^3^ HCHO, 6 hrs/d, 5 d/wk for 2 years | (Bermudez et al., 1994)
Deletion mutations
Mouse; Lymphoma L5178Y tk^+/-^ cells | 0.063 mM HCHO (commercial) | + | ND | 2 hrs; mouse lymphoma assay; cytotoxic at 250 µM conc. | (Speit and Merk, 2002)
Mouse; Lymphoma L5178Y tk^+/-^ cells | 0.8 mM 37% HCHO + 10% methanol | ND | + | 3 hrs; MF at TK locus; 40–50% total growth at 0.8 mM dose | (Mackerer et al., 1996)
Hamster; CHO cells/Hprt locus | 0.3 mM HCHO (37% w/w) | + | ND | 1 hr; 6-TG resistant mutants; dose-dependent ↓ in CFE and ↑ in MF | (Grafström et al., 1993)
Hamster; CHO cells/Hprt locus | 0.5 mM HCHO (commercial) | − | ND | 4 hrs; HPRT assay; (T) by relative CE ≥ 0.125 mM | (Merk and Speit, 1998)
Hamster; CHO cells/Hprt locus | 1 mM HCHO (40% aq. Sol.) | + | ND | 1 hr; 6-TG resistant colonies; base transversions at AT base pairs | (Graves et al., 1996)
Hamster; V79 lung epithelial cells | 0.5 mM HCHO (commercial) | − | ND | 4 hrs; HPRT assay; (T) by relative CE ≥ 0.25 mM | (Merk and Speit, 1999)
Human; Bronchial fibroblasts/epithe lial cells (HPRT locus) | 0.1 mM HCHO (commercial) | + | ND | 5 hrs; 6-TG resistant mutants scored; MF nonlinear dose-dependent ↑; (T) > 0.1 mM by CFE | (Grafstrom et al., 1985)
Human; Lymphoblasts/TK 6 | 0.03 mM 37% HCHO + 10-15% methanol | + | ND | 2 hrs; MF at TK locus measured; single exposure (0–150 µm) nonlinear ↑ in MF; (T) at 0.125 mM | (Craft et al., 1987)
Human; Lymphoblasts/TK 6 | 0.13 mM 37% HCHO + 10-15% methanol | + | ND | 2 hrs; MF at TK locus; cell survival was 15% at 0.15 mM; cells treated for 2 hrs with 0.07 mM methanol were not mutagenic, not cytotoxic | (Goldmacher and Thilly, 1983)
Human; Lymphoblasts/TK 6 | 0.15 mM HCHO (commercial) | + | ND | 8 exposures × 4 d, 2 hrs dosing; MF at HPRT locus; MF 12.4-fold higher over background; (T) 50% survival each treatment | (Crosby et al., 1988)
Point mutations
Mouse; Lymphoma cells/ TK+/- | 0.1 mM (-S9) and 0.5mM (+S9) 37% HCHO +10% methanol | +, − | +, − | NR; assay supplemented with FDH and NAD+; MF at the TK locus; results indicate without and with FDH/NAD^+^, respectively; 50% (T) at 0.1 mM (-S9) and 0.5 mM (+S9) with FDH | (Blackburn et al., 1991)
Mouse; Lymphoma cells/ TK+/- | 0.14 mM HCHO form not specified | + | ND | 4 hrs; MF at TK locus; highly mutagenic but total growth is very low | (Wangenheim and Bolcsfoldi, 1988)
Hamster; CHO cells/Hprt locus | 1 mM HCHO (40% aq. Sol.) | + | ND | 1 hr; 6-TG resistant colonies had base transversions at AT base pairs | (Graves et al., 1996)
Human; Lymphoblast/TK6 | 0.15 mM HCHO (commercial) | + | ND | 2 hrs (8 times); sequence analysis of HPRT mutants showed base substitutions at AT base pairs | (Liber et al., 1989)
DNA-protein crosslinks
Mouse Hepatocytes | 0.5 mM [^14^C] HCHO (aq. Sol.) | + | ND | 2 hrs; nonlinear dose-dependent ↑ in DPX. | (Casanova et al., 1997)
Mouse Hepatocytes | 0.5 mM [^14^C] HCHO (aq. Sol.) | + | ND | 2 hrs; HPLC analysis of DNA digest; Dose-dependent ↑ in DPX. | (Casanova and Heck, 1997)
Mouse; L5178Y tk^+/-^ Lymphoma cells | 0.031 mM HCHO (commercial) | + | ND | 2 hrs; DPX show dose-response; cytotoxic at 250 µM conc. | (Speit and Merk, 2002)
Mouse; Leukemia L1210 cells | 0.125 mM 37% HCHO | + | ND | 1 hr; (T) at 0.3 µM conc. | (Ross et al., 1981)
Mouse; Leukemia L1210 cells | 0.2 mM 37% HCHO | + | ND | 2.5 hrs; (T) ≥ 0.175 mM | (Ross and Shipley, 1980)
Mouse; Bone marrow mesenchymal cells | 0.125 mM HCHO (37%) | + | ND | 12 hrs; Alkaline comet assay; (T) from 0.175 mM to 0.2 mM | (She et al., 2013)
Rat; C18 tracheal epithelial cell line | 0.1 mM PFA in PBS | + | ND | 1.5 hrs; DPX analyzed by alkaline elution; (T) at 0.4 mM | (Cosma and Marchok, 1988)
Rat; Aortic endothelial cells | 0.5 mM HCHO (commercial) | + | ND | 1.5 hrs; K+/SDS assay; dose-dependent ↑ in DPX ≥ 2 hrs; (T) by LDH release at 2 mM | (Lin et al., 2005)
Rat; Primary tracheal epithelial cells | 0.05 mM PFA in PBS | + | ND | 1.5 hrs; DPX analyzed by alkaline elution; (T) > 0.2 mM | (Cosma and Marchok, 1988)
Rat; Primary tracheal epithelial cells | 3.34 mM HCHO/PBS | + | ND | 3 hrs; dose-dependent ↑ in DPX | (Cosma and Marchok, 1988)
Rat; Yoshida lymphosarcoma cells | 0.25 mM HCHO (36% sol) | + | ND | 4 hrs; alkaline elution assay; (T) ID_50_ 0.25 mM | (O’Connor and Fox, 1987)
Hamster; CHO cells | 0.125 mM HCHO (commercial) | + | ND | 2 hrs; BrdU incorporation-FPG technique; conc.-related ↓ DNA migration inhibition | (Lorenti Garcia et al., 2009)
Hamster; CHO cells | 0.2 mM HCHO (NS) | + | ND | 1.5 hrs; dose-dependent ↑ in DPX up to 2 mM HCHO; values visually determined from graph | (Zhitkovich and Costa, 1992)
Hamster; CHO cells | 0.25 mM HCHO (NS) | + | ND | 1.5 hrs; dose-dependent ↑ in DPX formation up to 2 mM HCHO; values visually determined from graph | (Olin et al., 1996)
Hamster; CHO cells | 0.5 mM HCHO (commercial) | + | ND | 1.5 hrs; alkaline elution assay; DPX showed dose-dependent ↑ (0.5–4.5 mM); 82% viability at 4.5 mM HCHO | (Marinari et al., 1984)
Hamster; V79 lung epithelial cells | 0.01 mM 16% HCHO (ultrapure methanol free) | + | ND | 1 hr; Comet assay; dose-dependent ↓ in DNA migration at HCHO ≥ 0.01 mM; | (Speit et al., 2007b)
Hamster; V79 lung epithelial cells | 0.025 mM 16% HCHO (ultrapure methanol free); | + | ND | 4 hrs; Comet assay; dose-dependent ↓ DNA migration; (T) at 0.2 mM by cell counts/proliferation index | (Speit et al., 2008a)
Hamster; V79 lung epithelial cells | 0.0625 mM HCHO (commercial) | + | ND | 4 hrs; Comet assay; dose-dependent ↑ migration inhibition (0.0625–0.5 mM); (T) by relative CE ≥ 0.25 mM | (Merk and Speit, 1999)
Hamster; V79 lung epithelial cells | 0.125 mM HCHO (commercial) | + | ND | 4 hrs; K-SDS assay; nonlinear dose-dependent ↑ in DPX (values visually determined from graph); HCHO (T) by relative CE assay ≥ 0.125 | (Merk and Speit, 1998)
Human; Nasal epithelial cells | 0.2 mM 16% HCHO (ultrapure methanol free) | + | ND | 1 hr; Comet assay; dose-dependent ↑ DPX from 0.05–0.3 mM; (T) by CF ≥ 0.02 mM | (Speit et al., 2008b)
Human; A549 lung epithelial cells | 0.2 mM 16% HCHO (ultrapure Methanol free) | + | ND | 1 hr & 4 hrs; Comet assay; dose-dependent ↑ migration inhibition from 0.1–0.3 mM; (T) by CF ≥ 0.02 mM | (Speit et al., 2008b)
Human; A549 lung epithelial cells | 0.2 mM HCHO (stabilized with methanol) | + | ND | 3 hrs; KCl/SDS method; DPX time-dependent ↑ up to 12 hrs; T^1^/_2_ 12.5 hrs; (T) ≥ 0.2 mM by CF assay | (Quievryn and Zhitkovich, 2000)
Human; A549 lung epithelial cells | 0.2 mM 16% HCHO (aqueous solution, methanol-free) | + | ND | 1 or 3 × 24 hr intervals; comet assay | (NTP, 2010)
Human; Lung/bronchial epithelial cells | 0.1 mM HCHO (commercial) | + | ND | 1 hr; alkaline elution technique; (T) 0.021 mM ID_50_ by growth inhibition | (Saladino et al., 1985)
Human; Lung/bronchial epithelial cells | 0.1 mM HCHO (commercial) | + | ND | 1 hr; alkaline elution technique; (T) at 0.3 mM by CFE | (Grafstrom et al., 1986)
Human; Lung/bronchial epithelial cells | 0.2 mM 37% HCHO (w/w) | + | ND | 1 hr; alkaline elution technique; (T) at 1 mM | (Grafstrom et al., 1984)
Human; Lung/bronchial epithelial cells | 2 mM HCHO (Not Specified) | + | ND | 1 hr; Alkaline elusion technique; | (Grafstrom, 1990)
Human; Lung/bronchial epithelial cells | 0.39 mM HCHO | + | ND | 4 hrs; KCl-SDS method | (Duan, 2011)
Human; Lung/bronchial epithelial cells | 0.8 mM 37% HCHO | + | ND | 1 hr; alkaline elution | (Fornace et al., 1982)
Human; Bronchial epithelial cells/fibroblasts | 0.1 mM 37% HCHO | + | ND | 1 hr; alkaline elution technique | (Grafstrom et al., 1983)
Human; Fibroblasts (diploid)/HF/SV40 | 0.2 mM HCHO + Methanol) | + | ND | 3 hrs; (T) ≥ 0.2 mM by CF assay; DPX half-life is 12.5 hrs | (Quievryn and Zhitkovich, 2000)
Human; Fibroblast (Bronchial/Skin) | 0.25 mM HCHO (NS) | + | ND | 1.5 hrs; DPX dose-response not prominent; values visually determined from graph | (Olin et al., 1996)
Human; Skin keratinocytes/ fibroblasts | 0.025 mM HCHO (NS) | + | ND | 8 hrs with subsequent exposure to methyl methane sulfonate (0.25 mM) | (Emri et al., 2004)
Human; XP fibroblasts | 0.2 mM 37% HCHO (w/w) | + | ND | 1 hr; alkaline elution technique; DPX T^1^/_2_ 2–3 hrs | (Grafstrom et al., 1984)
Human; Normal, XPA and FA repair deficient fibroblasts | 0.125 mM HCHO (commercial) | + | ND | 2 hrs; Comet assay; dose-dependent DNA migration inhibition; No migration inhibition after 24 hrs | (Speit et al., 2000)
Human; Fibroblasts/XP-F and XP-A | 0.2 mM HCHO (stabilized with Methanol) | + | ND | 3 hrs; DPX removal XP-A = XP-F cells; (T) ≥ 0.2 mM by CF assay | (Quievryn and Zhitkovich, 2000)
Human Lymphocytes | 0.05 mM 10% formalin | + | ND | 1 hr; comet assay; KCl/SDS assay; nonlinear dose-dependent ↑ ≥ 50 µM HCHO | (LICM, 2006)
Human Lymphocytes | 0.1 mM; 0.3 mM HCHO in water | + | − | 3 hrs; (T) at 0.3 mM (+S9) | (Andersson et al., 2003)
Human Lymphocytes | 0.2 mM HCHO + Methanol) | + | ND | 3 hrs; KCl/SDS method; DPX T^1^/_2_ 18.1 hrs; (T) ≥ 0.2 mM by CF assay | (Quievryn and Zhitkovich, 2000)
Human; White blood cells | 0.001 mM HCHO (NS) | + | ND | 1.5 hrs; Dose-dependent ↑ in DPX formation up to 2 mM HCHO; values visually determined from graph | (Shaham et al., 1996)
Human; Whole blood cultures | 0.025 mM 16% HCHO (ultrapure Methanol free) | + | ND | exposure duration not specified; Comet assay; dose-dependent migration inhibition; DPX ≥ 0.2 mM persist for 24 hrs | (Schmid and Speit, 2007)
Human; Lymphoblast/TK6 | 0.05 mM 37% HCHO + 10-15% Methanol | + | ND | 2 hrs; MF at TK locus measured; (T) at 0.125 mM | (Craft et al., 1987)
Human; Lymphoblast/TK6 | 0.1 mM 16% HCHO (ultrapure MetOH free) | + | ND | 2 hrs; Comet assay with g-irradiation; DPX formation dose-dependent; (T) at 0.1 mM 24 hrs by MTT assay | (Kuehner et al., 2013)
Human; lymphoblasts (PD20 & PD20-D2) | 0.125 mM 37% HCHO | + | ND | 24 hrs; Dose-dependent ↑ in DPX from 0.05-0.15 mM; PD20>PD20-D2; (T) >0.15 mM | (Ren et al., 2013)
Human; EBV-Burkitt’s lymphoma cells | 0.03% PFA in water | + | ND | 18 hrs; Dose-dependent ↑ in DPX; (T) 0.01% PFA | (Costa et al., 1997)
Human; T-leukemia (Jurkat E6-1) cells | 1 mM HCHO (commercial) | + | ND | 2 hrs; SDS-PAGE; (T) ≥ 1 mM by cell death assay | (Saito et al., 2005)
Human; HeLa cells | 0.05 mM; 10% formalin | + | ND | 1 hr; KCl/SDS precipitation method; (T) ≥ 100 mM by absorbance after 12 hrs; dose-dependent ↑ in DPX; repaired within 18 hrs after HCHO removal | (LICM, 2006)
Human; Kidney cells/Ad293 | 0.2 mM HCHO + Methanol | + | ND | 3 hrs; KCl/SDS method; DPX T^1^/_2_ 12.5 hrs; (T) ≥ 0.2 mM by CF assay | (Quievryn and Zhitkovich, 2000)
Human; Gastric mucosa cells | 1 mM HCHO | + | ND | 1 hr; (T) not reported | (Blasiak et al., 2000)
DNA adducts
Hamster CHO cells | 1 mM [^3^H] 37% HCHO/10-15% Methanol | + | ND | 2 hrs; (T) ≥ 2.5 mM | (Beland et al., 1984)
Human; Nasal epithelial cells | 0.33 mM 37% HCHO + 10% Methanol | + | ND | 24 hrs; hmdA and hmdG adducts dose-dependent ↑. Viability showed dose-dependent from 10 500 mM; | (Zhong and Que Hee, 2004)
Human; HeLa cells | 0.5 mM [^13^CD_2_]HCHO (20% in heavy water) | + | ND | 3 hrs; No (T) information provided | (Lu et al., 2012a)
Chromosomal aberrations (CA)
Hamster; CHO cells (AA8) and their mutants (UV4, UV5, UV61) | 0.15 mM HCHO (commercial) | + | ND | 2 hrs; BrdU incorporation-FPG technique; dose-dependent ↑ in Cas | (Lorenti Garcia et al., 2009)
Hamster CHO cells | 0.2 mM PFA in water | + | + | 2 hrs; BrdU incorporation; dose-dependent ↑ in SCE +/− S9 | (Natarajan et al., 1983)
Hamster; CHO cells mutants (KO40) | 0.2 mM HCHO (commercial) | + | ND | 2 hrs; BrdU incorporation-FPG technique; dose-dependent ↑ in CAs | (Lorenti Garcia et al., 2009)
Hamster; CHO cells | 0.53 mM HCHO | (+) | (+) | 8–12 hrs; Giemsa staining | (Galloway et al., 1985)
Hamster; Lung fibroblasts | 0.6 mM Formalin | + | ND | 24 hrs; microscopic evaluation | (Ishidate et al., 1981)
Hamster/Syrian Embryo cells | 0.033 mM 37% HCHO + 7–13% Methanol | + | ND | 24 hrs; CA assay; 85% relative CFE at 0.099 mM | (Hikiba et al., 2005)
Human; Fibroblasts | 2 mM HCHO (NS) | + | ND | 0.25 hr; Giemsa staining; dose-dependent ↑ in CA | (Levy et al., 1983)
Human Lymphocytes | 0.125 mM HCHO (NS) | + | ND | 1 hr; PCC technique; dose-dependent↑ in CA | (Dresp and Bauchinger, 1988)
Human; lymphoblasts (PD20 & PD20-D2) | 0.125 mM 37% HCHO | + | ND | 24 hrs; Dose-dependent ↑ in CA from 0.05-0.15 mM; PD20=PD20-D2; (T) >0.15 mM | (Ren et al., 2013)
Human; lymphocytes | 0.25 mM, 0.5 M 37% HCHO + 10% Methanol | + | + | 1 hr; conc. Respectively, for chromatid breaks and gaps; proliferation inhibition at 1 M (−S9) and 0.5 mM (+S9) | (Schmid et al., 1986)
Micronucleus (MN)
Mouse; erythropoietic cells | 0.025 mM HCHO (37% + 10-15% methanol) | + | ND | 1 hr; Dose-dependent in MN from 0.025-0.1 mM | (Ji et al., 2014)
Hamster; V79 lung epithelial cells | 0.075 mM 16% HCHO (ultrapure Methanol free); | + | ND | 2 hrs; MN test; MN ≥ 0.075 mM; dose-dependent ↑ in MN | (Speit et al., 2007b)
Hamster; V79 lung epithelial cells | 0.1 mM 16% HCHO (ultrapure Methanol-free); | + | ND | 4 hrs; MN test; dose-dependent in MN; (T) at 0.2 mM by cell counts/proliferation index | (Speit et al., 2007b)
Hamster; V79 lung epithelial cells | 0.125 mM HCHO (commercial) | + | ND | 4 hrs; MN assay with AO staining; nonlinear dose-dependent ↑ in MN (values visually determined from graph); (T) by relative CE ≥ 0.125 mM | (Merk and Speit, 1998)
Human; A549 lung epithelial cells | 0.15 mM 16% HCHO (ultrapure, methanol-free) | + | ND | 2 hrs (0.3 mM) or 30 hrs (0.15 mM); CBMN assay; Mostly centromere -ve by FISH analysis | (Speit et al., 2011a)
Human; Normal, XPA and FA repair deficient fibroblasts | 0.125 mM HCHO (commercial) | + | ND | 2 hrs; MN test; MN ≥ 0.075 mM; dose-dependent ↑ in MN; normal<XPA<FA | (Speit et al., 2000)
Human; lymphoblasts (PD20 & PD20-D2) | 0.125 mM 37% HCHO | + | ND | 24 hrs; Dose-dependent ↑ in MN from 0.05-0.15 mM;PD20>PD20-D2; (T) >0.15 mM | (Ren et al., 2013)
Human; Whole blood cultures | 0.3 mM 16% HCHO (ultrapure, methanol-free) | + | ND | 27 hrs; CBMN assay; mostly centromere negative by FISH analysis | (Speit et al., 2011a)
Human; Whole blood cultures | 0.3 mM 16% HCHO (ultrapure Methanol free); | + | ND | 24 hrs; HCHO dosed 44 hrs after culture; MN test; dose-dependent ↑ in MN (0.1–0.4 mM); (T) ≥ 0.3 mM by NDI | (Schmid and Speit, 2007)
Single strand breaks (SSB)
Mouse; Leukemia L1210 cells | 0.125 mM 37% HCHO | − | ND | 1 hr; (T) at 0.3 mM | (Ross et al., 1981)
Mouse; Leukemia L1210 cells | 0.2 mM 37% HCHO | (+) | ND | 2.5 hrs; (T) ≥ 0.175 mM | (Ross and Shipley, 1980)
Rat; Hepatocytes | 1 mM HCHO (NS) | + | ND | 4 hrs; HCHO cytotoxic ≥1.5 mM; dose-dependent ↑ in SSB, enhanced by GSH depletion | (Demkowicz-Dobrzanski and Castonguay, 1992)
Rat -tracheal epithelial cell line | 0.2 mM PFA in PBS | + | ND | 1.5 hrs; SSB analyzed by alkaline elution; HCHO toxic at 0.4 mM | (Cosma and Marchok, 1988)
Rat; Yoshida lymphosarcoma cells | 0.25 mM HCHO (36% sol) | + | ND | 4 hrs; alkaline elution assay; (T) ID_50_ 0.25 mM | (O’Connor and Fox, 1987)
Hamster CHO cells | 4.5 mM HCHO (commercial) | − | ND | 1.5 hrs; 82% viability at 4.5 mM HCHO | (Marinari et al., 1984)
Hamster; V79 lung epithelial cells | 0.2 mM 16% HCHO (ultrapure Methanol free) | − | ND | 1 hr; Comet assay | (Speit et al., 2007b)
Human; Bronchial epithelial cell | 0.1 mM 37% HCHO | + | ND | 1 hr; alkaline elution technique; (T) at 0.3 mM | (Grafstrom et al., 1983)
Human; Bronchial epithelial cell | 0.3 mM 37% HCHO (w/w) | + | ND | 1 hr; SSB dose-dependent ↑; SSB 3 times higher than XP cells | (Grafstrom et al., 1984)
Human; Lung/bronchial epithelial cells | 0.1 mM HCHO (commercial) | + | ND | 1 hr; alkaline elution technique; (T) 0.021 mM ID_50_ by growth inhibition | (Saladino et al., 1985)
Human; Lung/bronchial epithelial cells | 0.1 mM HCHO (commercial) | + | ND | 1 hr; alkaline elution technique; (T) at 0.3 mM by CFE | (Grafstrom et al., 1986)
Human; Lung/bronchial epithelial cells | 0.8 mM 37% HCHO | + | ND | 1 hr; alkaline elution | (Fornace, 1982)
Human; Lung/bronchial epithelial (A549) cells | 1.0 mM HCHO (commercial) | + | ND | 8–72 hrs; Dose-dependent in ↑ DSB formation; DSB formed when viability, determined by MTT assay, was >60% | (Vock et al., 1999)
Human; Skin keratinocytes/ fibroblasts | 0.1 mM HCHO (NS) | − | ND | 20 hrs | (Emri et al., 2004)
Human; XP fibroblasts | 0.3 mM 37% HCHO (w/w) | + | ND | 1 hr; SSB dose-dependent ↑ | (Grafstrom et al., 1984)
Human; Foreskin fibroblasts | 0.1 mM 37% HCHO + 10% Methanol | + | ND | 0.5 hr; nick translation assay; low doses induce SSB | (Snyder and van Houten, 1986)
Human; Foreskin fibroblasts | 0.25 mM 37% HCHO + 10% Methanol | − | ND | 0.5 hr; alkaline sucrose sedimentation analysis; high doses don’t induce SSB | (Snyder and van Houten, 1986)
Human; HeLa cells | 0.005 mM 10% formalin | + | ND | 1 hr; Comet assay; (T) ≥ 100 µM after 12 hrs; SSB repaired within 90 min | (LICM, 2006)
Human; Lymphocytes, peripheral blood | 0.005 mM 10% formalin | + | ND | 1 hr; comet assay; KCl/SDS assay; nonlinear dose-dependent ↑ ≥ 50 µM HCHO | (LICM, 2006)
Sister chromatid exchanges (SCE)
Hamster; CHO cells | 0.03 mM 37% HCHO with 10% methanol | + | ND | 24 hrs; BrdU incorporation; SCE dose-dependent ↑ | (Obe and Beek, 1979)
Hamster; CHO cells | 0.04 mM HCHO (commercial) | (+) | (+) | 26 hrs; BrdU incorporation-FPG technique | (Galloway et al., 1985)
Hamster; CHO cells | 0.2 mM PFA in water | + | + | 2 hrs; BrdU incorporation; dose-dependent ↑ in SCE +/− S9 | (Natarajan et al., 1983)
Hamster; CHO cells (AA8) and their mutants (UV4, UV5, UV61, KO40) | 0.15 mM HCHO (commercial) | + | ND | 2 hrs; BrdU incorporation-FPG technique; dose-dependent ↑ in CAs | (Lorenti Garcia et al., 2009)
Hamster; Embryo cells | 0.01 mM 37% HCHO/7–13% Methanol; | + | ND | 24 hrs; BrdU incorporation; dose-dependent ↑ in SCE; (T) by relative CE 68% at 0.033 mM | (Miyachi and Tsutsui, 2005)
Hamster; V79 lung epithelial cells | 0.05 mM 16% HCHO (ultrapure, methanol-free) | + | ND | 24 or 28 hrs exposure to HCHO and BrdU; Aneuploidy and Toxicity measured by SCE and PI, respectively | (Speit et al., 2011a)
Hamster; V79 lung epithelial cells | 0.06 mM 37% HCHO with 10% methanol | + | − | 28 hrs; formalin + activation with primary rat hepatocytes; (T) at 0.54 mM (+S9) and 0.2 mM (−S9) | (Basler et al., 1985)
Hamster; V79 lung epithelial cells | 0.1 mM 16% HCHO (ultrapure Methanol free); | + | ND | 2 hrs; BrdU labeling; SCE ≥ 0.1 mM; genotoxicity paralleled cytotoxicity; (T) ≥ 0.1 mM by PI | (Speit et al., 2007b)
Hamster; V79 lung epithelial cells | 0.1 mM 16% HCHO (ultrapure Methanol free); | + | ND | 1 hr; BrdU labeling; SCE dose-dependent ↑ (0.1-0.2 mM) | (Neuss and Speit, 2008)
Hamster; V79 lung epithelial cells | 0.1 mM 16% HCHO (ultrapure Methanol free); | + | ND | 4 hrs; BrdU labeling; dose-dependent in SCE; (T) at 0.2 mM by cell counts/proliferation index | (Speit et al., 2008a)
Hamster; V79 lung epithelial cells | 0.125 mM HCHO (commercial) | + | ND | 4 hrs; BrdU incorporation; dose-dependent ↑ in SCE; (T) by relative CE ≥ 0.125 mM | (Merk and Speit, 1998)
Hamster; V79 lung epithelial cells | 0.125 mM HCHO (commercial) | + | ND | 4 hrs; BrdU incorporation; dose-dependent ↑ in SCE; (T) by relative CE ≥ 0.25 mM | (Merk and Speit, 1999)
Hamster; V79 lung epithelial cells | 0.13 mM 37% HCHO with 10% methanol | + | ND | 2 hrs; (T) at 0.54 mM | (Basler et al., 1985)
Hamster; V79 lung epithelial cells | 0.13 mM; 0.20 mM 37% HCHO with 10% methanol | + | − | 3 hrs; (T) at 0.4 mM (−S9) | (Basler et al., 1985)
Human; A549 lung epithelial cells | 0.1 mM 16% HCHO (ultrapure Methanol free); | + | ND | 1 hr; BrdU labeling; SCE dose-dependent ↑ (0.1–0.3 mM) | (Neuss and Speit, 2008)
Human; A549 + V79 cells (co-cultivated) | 0.05 mM 16% HCHO (ultrapure Methanol free); | + | ND | 1 hr; BrdU labeling; SCE dose-dependent ↑ (0.05–0.2 mM); treated A549 cells not washed before adding V79 cells | (Neuss and Speit, 2008)
Human; A549 + V79 cells (co-cultivated) | 0.3 mM 16% HCHO (ultrapure Methanol free); | − | ND | 1 hr; BrdU labeling; treated A549 cells washed before adding V79 cells | (Neuss and Speit, 2008)
Human Lymphocytes | 0.125 mM 37% HCHO + 10% Methanol | + | + | 1 hr; BrdU labeling; proliferation inhibition at 1 M (-S9) and 0.5 mM (+S9) | (Schmid et al., 1986)
Human Lymphocytes | 0.167 mM 37% HCHO + 10% Methanol | + | ND | 24 hrs; BrdU incorporation; dose-dependent ↑ in SCE | (Obe and Beek, 1979)
Human Lymphocytes | 0.167 mM formalin or PFA | + | ND | 72 hrs; BrdU incorporation with fluorescence + Giemsa method; (T) ≥0.33 mM and similar for formalin and PFA; dose-dependent ↑ for formalin reported | (Krieger et al., 1983)
Human; Whole blood cultures | 0.2 mM 16% HCHO (ultrapure Methanol free) | + | ND | 72 hrs; BrdU labeling; no dose-response; (T) at 0.2 mM by PI | (Schmid and Speit, 2007)
Unscheduled DNA synthesis (UDS)
Rat; Hepatocytes | 400 mM HCHO (NS) | + | ND | 18–20 hrs; [^3^H]dThd incorporation and autoradiography | (Williams et al., 1989a)
Human; Bronchial epithelial cells | 0.1 mM 37% HCHO (reagent grade sol.) | − | ND | 22 hrs; [^3^H]dThd incorporation and autoradiography; (T) ≥ 1 mM | (Doolittle et al., 1985)
Human; Foreskin fibroblasts | 0.5 mM 37% HCHO + 10% Methanol | − | ND | 0.5 hr; UDS | (Snyder and van Houten, 1986)
Human; Bronchial fibroblasts | 1 mM 37% HCHO | − | ND | 1 hr; [^3^H-Thymidine] incorporation. | (Grafstrom et al., 1983)
Human; Embryo cells | 0.1 mM HCHO (37% sol) | + | ND | 1 hr; [^3^H]dThd incorporation; dose-dependent ↑ in UDS (0.1-1 mM) | (Hamaguchi and Tsutui, 2000)
Human; HeLa cells | 0.001 mM HCHO (commercial) | + | ND | 2.5 hrs; [^3^H]dThd incorporation | (Martin et al., 1978)
DNA repair inhibition
Human; Skin keratinocytes/fibr oblasts | 0.01 mM HCHO (NS) | + | ND | 0.5 hr after exposure to UVB | (Emri et al., 2004)
Human; Normal, XPA and FA repair deficient fibroblasts | 0.125 mM HCHO (commercial) | + | ND | 2 hrs | (Speit et al., 2000)
Cell transformation
Mouse; Embryo fibroblast/C3H10T ^1^/_2_ cells | 0.003 mM HCHO (37%) | + | ND | 24 hrs; HCHO treatment followed by TPA treatment, transformation +ve and dose-dependent; (T) ≥ 0.017 mM | (Boreiko and Ragan, 1983)
Mouse; Embryo fibroblast/C3H10T ^1^/_2_ cells | 0.017 mM HCHO (37% w/w) exposure | + | ND | 24 hrs HCHO, 6 wks to medium ± TPA. HCHO +TPA +ve, dose-dependent ↑ (0.017–0.34 mM); HCHO alone −ve (0.083 mM); methano + TPA or formic acid + TPA −ve. HCHO cytotoxic at 0.033 mM | (Ragan and Boreiko, 1981)
Mouse; Embryo fibroblast/C3H10T ^1^/_2_ cells | 0.033 mM HCHO (37% w/w) exposure; | [+] | ND | 4 hrs initiation with 0.5 µg/mL MNNG, promotion on days 5, 8, 15, 22, 29, 36 with HCHO with change of medium | (Frazelle et al., 1983)
Hamster; Kidney cell/BHK-21/cI.13 | 0.03 mM HCHO 37% aq.sol. | + | + | 3 hrs; Style’s cell transformation assay; transformation dose-dependent ↑ (0.03–0.67 mM); (T) ≥ 0.67 mM | (Plesner and Hansen, 1983)
Aneuploidy
Hamster; CHO cells (WT & XPF-deficient) | 0.3 mM HCHO (Not Specified) | + | ND | 4 hrs; Wright’s stain and G-banding; +ve for tetraploidies and polyploidies | (Kumari et al., 2012)
Hamster; V79 lung epithelial cells | 0.05 mM HCHO, 16% ultra-pure, methanol-free | − | ND | 7 d exposure; FISH analysis; (T) at 0.05 mM by CFA | (Kuehner et al., 2012)
Hamster; V79 lung epithelial cells | 0.1 mM HCHO, 16% ultra-pure, methanol-free | − | ND | 24 or 28 hrs exposure to HCHO and BrdU; Aneuploidy and Toxicity measured by SCE and PI, respectively | (Speit et al., 2011a)
Human; A549 lung epithelial cells | 0.05 mM HCHO, 16% ultra-pure, methanol-free | − | ND | 14 d exposure; FISH analysis; (T) at 0.02 mM by CFA | (Kuehner et al., 2012)
Human; myeloid progenitor cells | 0.05 mM HCHO, 16% ultra-pure, methanol-free | − | ND | 9 d exposure; Aneuploidy in chromosomes 6, 7, and 8 tested by FISH analysis; (T) at 0.1 mM by CFA | (Kuehner et al., 2012)
Human; erythropoietic stem cells | 0.05 mM HCHO (37% +10–15% methanol) | + | ND | 5 d; FISH analysis; Combined analysis of monosomies or trisomies of 7 and 8 are positive | (Ji et al., 2014)

a Lowest effective concentration (LEC) for positive results or highest ineffective concentration tested (HIC) for negative or equivocal results.

b + = positive; − = negative; (+), equivocal.

6-TG, 6-thioguanine; CF, colony formation; FA, Fanconi anemia; FDH, formaldehyde dehydrogenase; FPG, fluorescence plus Giemsa technique; HCHO, formaldehyde; hmdA, hydroxymethyl-deoxyadenosine; hmdG, hydroxymethyl-deoxyguanosine; hmDNA, hydroxymethyl-DNA; HPRT, hypoxanthine phosphoribosyl transferase; ID_50_, HCHO concentration causing 50% growth inhibition compared to control cells; MF, mutation frequency; MN, micronucleus; NAD, nicotinamide adenine dinucleotide; ND, not done; NDI, nuclear division index; NR, not reported; NS, not specified; PFA, paraformaldehyde; PCC, premature chromosome condensation; PI, proliferation index; SCC, squamous cell carcinoma; SCE, sister chromatid exchange; (T), toxicity or cytotoxicity; TK, thymidine kinase; XP, xeroderma pigmentosum; AA8, parental CHO cells; CHO cell mutants deficient in nucleotide excision repair (UV4 & UV5), or transcription-coupled repair (UV61) or crosslink repair-deficient (KO40).

#### Summary of in vitro genotoxicity of formaldehyde

In vitro genotoxicity of formaldehyde has been reported in several mammalian cell culture systems (see Table C-17). Formaldehyde is mutagenic in several mouse lymphoma cells, Chinese hamster ovary (CHO) and hamster lung epithelial (V79) cells, a human lung epithelial carcinoma (A549) cell line, fibroblasts, gastric mucosa cells, and human peripheral blood lymphocytes (PBLs) and lymphoblasts. As shown in Table C-17, several genotoxicity endpoints, such as DNA-protein crosslinks, hydroxymethyl-DNA adducts, single strand breaks, cytogenetic markers, such as micronucleus, chromosomal aberrations, and sister chromatid exchanges, and other genotoxic end points, such as unscheduled DNA synthesis, DNA repair inhibition, and cell transformation have been demonstrated in animal and human cell systems.

Cell lines derived from formaldehyde-induced rat nasal squamous cell carcinomas showed p53 mutations and the mutant cells were tumorigenic when injected in nude mice, suggesting the mutagenicity and carcinogenicity of formaldehyde. Further, formaldehyde induced deletions and point mutations at the thymidine kinase (tk) locus in cultured mouse lymphoma cells and human lymphoblasts or at the hypoxanthine phosphoribosyl transferase (hprt) locus in CHO and V79 cells, and the mutations showed a dose-dependent increase. Further, these mutations contained base substitutions at the AT base pairs at both these loci.

Evidence of formaldehyde-induced genotoxicity was observed in rodent and human cells wherein a dose-dependent increase in DPX formation was reported over a range of formaldehyde concentrations (0.01–0.0625 mM) (see Table C-17). DPX are formed within an hour of exposure and removed within 24 hours after formaldehyde removal in cultured human cells. The average half-life (t_1/2_) of DPX is 2–3 hours in xeroderma pigmentosum (XP) fibroblasts, 12.5 hours in Ad293 kidney cells and A549 cells, and 18.1 hours (range 1–60 hours) in PBLs. The higher removal time in PBLs is either due to low levels of glutathione in lymphocytes or inefficient repair. Thus, the existing data suggest that repair of DPX depends on the cell type. The removal of DPX is carried out either by spontaneous hydrolysis or other DNA repair processes; however, no difference in DPX removal has been observed between normal human fibroblasts and fibroblasts from XP or Fanconi anemia cell lines, suggesting a lack of involvement of nucleotide excision repair in the repair process. In proliferating cells, unrepaired DPX can arrest DNA replication and lead to the induction of other genotoxic effects such as SCEs. Further evidence of DNA reactivity was observed in CHO cells, HeLa cells, and human nasal epithelial cells wherein formaldehyde induced hm-DNA adducts.

Among the other types of genotoxicity, formaldehyde induced SSBs in several mammalian cell systems, including mouse leukemia cells; rat primary hepatocytes, tracheal epithelial cells, and lymphosarcoma cells; and human lung/bronchial epithelial cells, A549 and HeLa cells, skin fibroblasts, and PBLs, within an hour of exposure (see Table C-17). It has been shown that SSBs can be formed directly in lung/bronchial epithelial cells with formaldehyde exposure, independent of DNA repair.

Several studies have demonstrated formaldehyde-induced cytogenetic markers (CAs, MN and SCEs) in different rodent and human primary cells and cell lines (see Table C-17). For example, CAs are induced in CHO cells (normal and DNA repair deficient), V79 cells, and hamster embryo cells, with a dose-dependent increase in human fibroblasts and lymphocytes. Further evidence exists for formaldehyde-induced clastogenic effect as observed by MN induction in V79 cells and a dose-dependent increase in MN induction in both human whole blood cultures and normal and repair deficient fibroblast cells. Furthermore, formaldehyde induced SCEs in CHO cells (normal and repair-deficient) and V79 cells at various concentrations (0.01–0.5 mM). The dose-dependent increase in SCE was higher in mutant CHO cells compared to the normal counterparts, suggesting the importance of DNA repair in SCE removal. Exposure of A549 cells for 1 hour with formaldehyde or co-culturing the exposed A549 cells with unexposed V79 cells beyond 1 hour induces SCE in both cell types, suggesting that formaldehyde is active in the medium for a longer time and continues to induce genotoxicity despite the high reactivity of formaldehyde with macromolecules.

In addition, formaldehyde induces DNA repair inhibition in normal as well as repair-deficient fibroblasts derived from XP and Fanconi anemia patients. In mouse embryo fibroblasts, formaldehyde acts as a potential initiator with a dose-dependent increase in cell transformation but acts as a weak promoter in hamster kidney cells. Overall, there is significant evidence that formaldehyde is genotoxic and mutagenic in several human and rodent cell culture systems.

### C.3.5 Genotoxicity of Formaldehyde in Experimental Animals

In experimental animals, formaldehyde has been shown to induce DNA adducts, DPXs, DDXs, SSBs, cytogenetic alterations, such as, MN, SCEs, CAs, and mutations, as summarized in Tables C-18 and C-19.

#### DNA reactivity and DNA damage

Formaldehyde is highly DNA reactive. Based on numerous experimental animal studies across several species, exposure has been shown to cause damage at the site of contact and/or portal of entry (POE), including the formation of DNA adducts, DPXs, DDXs, SSBs and other cytogenetic effects (see Tables C-18 and C-19). In addition, some animal studies have reported evidence of effects on DNA at sites distal to the POE; however, these observations were not highly consistent across the available studies (acknowledging that the primary focus of most studies was the POE), and interpretations are complicated by the frequent use of test articles presumed to introduce methanol co-exposure (see Tables C-18 and C-19). This limitation is of significant concern for changes observed outside of the POE.

##### DNA adducts

Beland et al. (1984) demonstrated the formation of hmDNA mono adducts (e.g., N^6^-hmdA) from the in vitro reaction of formaldehyde with calf thymus DNA (see Appendix C.3.4). The hmDNA adducts are labile in nature and hence they were detected as methylDNA (me-DNA) adducts after chemically reducing them with NaBH_3_CN followed by LC/MS analysis (Wang et al., 2007b; Wang et al., 2009a; Moeller et al., 2011; Lu et al., 2010a; Lu et al., 2011). Using [^13^CD_2_]-formaldehyde inhalation exposures or orally administered [^13^CD_4_]-methanol, one research group has reported the development of an LC/MS method that distinguishes formaldehyde-induced hmDNA mono adducts and DNA-DNA crosslinks originating from endogenous and exogenous exposures in different tissues of rats (Lu et al., 2010a; Lu et al., 2011; Lu et al., 2012b) and monkeys (Moeller et al., 2011). Lu et al. (2010a) exposed F344 rats to a single dose of 12.3 mg/m^3^ ^13^CD_2_-formaldehyde by inhalation for 1 and 5 days. The authors detected three forms of endogenous DNA damage, i.e., the N^2^-hmdG and N^6^-hmdA mono adducts and dG-CH_2_-dG crosslinks, in all tested tissues (nose, lung, liver, spleen, bone marrow, thymus, and blood). The exogenous N^2^-hmdG adduct and dG-CH_2_-dG crosslinks were detectable only in nasal tissue and their levels increased from 1 day to 5 days of exposure. However, the exogenous N^6^-hmdAdo adducts were not detectable in any of the tissues analyzed (Lu et al., 2010a).

The same group of investigators also exposed F344 rats to inhaled [^13^CD_2_]-formaldehyde (0.9 to 18.7 mg/m^3^) for 6 hours and measured N^2^-hmdG adducts in the nasal epithelium (Lu et al., 2011). While both the endogenous and exogenous hmDNA adducts were analyzed in exposed rats, this study did not report the use of unexposed controls. Compared to the ^13^C-labeled exogenous mono adducts formed by exposures up to 11.2 mg/m^3^, endogenous N^2^-hmdG adducts formed at levels between 1.7 and over 90-fold higher, showing considerable variation in adduct levels across doses. Although the exogenous N^2^-hmdG adducts exhibited a nonlinear increase over the range of concentrations tested, their levels appeared to be above endogenous levels only at the highest formaldehyde concentration tested.

Further, the same group of investigators studied the distribution of hmDNA adducts in Cynomolgus monkeys that were exposed by inhalation to 2.34 or 7.5 mg/m^3^ of ^13^CD_2_-formaldehyde (6 hours/day for 2 days) (Moeller et al., 2011). Endogenous N^2^-hmdG mono adducts were detected in the nasal maxilloturbinates and bone marrow, but exogenous DNA adducts were only detectable in the maxilloturbinates. The endogenous tissue levels of hmDNA adducts were 5–10 fold higher than corresponding exogenous adduct levels.

Recently, another study from the same research group examined endogenous and exogenous hm-DNA adducts in rats exposed to low levels of [^13^CD_2_]-formaldehyde (1, 30, and 300 ppb) by nose-only inhalation for 28 days (Leng et al., 2019). The authors reported detectable levels of endogenous, but not exogenous hm-DNA adducts in several tissues including those in lower or upper respiratory tract (nasal epithelium, trachea and lung), blood and bone marrow, and in tissues other than respiratory tract, bone marrow and blood cells. Thus, any exogenous formaldehyde-induced hm-DNA adducts are below the limit of detection for exposure concentrations up to 300 ppb (Leng et al., 2019).

In addition to inhalation exposures, hmDNA adducts have been measured after exposure to chemicals (i.e., nitrosamines, methanol) that are metabolized to formaldehyde (Wang et al., 2007b; Lu et al., 2012b). Wang et al. (2007b) have detected the N^6^-hmdA adduct in the liver and lung of rats injected subcutaneously with the tobacco-specific nitrosamines, N-nitrosodimethylamine (NDMA), or 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone (NNK) at 0, 0.025, and 0.01 mmol/kg b.w. doses. The N^6^-hmdA adduct showed a dose-response formation with both nitrosamines and was also detected endogenously in saline controls, albeit at low levels. Compared to saline controls, N^6^-hmdA levels in exposed rats were 4.5- to 15-fold higher in the liver, and 2.2- to 3.8-fold higher in the lung. Following gavage exposure with 500 and 2,000 mg/kg [^13^CD_4_]-labeled methanol, hmDNA adducts were detectable in several tissues of Sprague-Dawley rats, including bone marrow (Lu et al., 2012b). In this study, the authors also analyzed an unexposed control group. A dose-dependent increase in exogenous N^2^-hmdG adducts was reported in several tissues including bone marrow, suggesting that exogenous methanol is transported to bone marrow where it is converted to formaldehyde and results in the formation of exogenous hmDNA adducts that are identical to endogenous formaldehyde mono adducts. Interestingly however, the levels of endogenous N^2^-hmdG adducts, but not N^6^-hmdA adducts, in methanol-exposed animals were significantly increased in several tissues compared to endogenous N^2^-hmdG adduct levels in the corresponding tissues of unexposed controls. This observation suggests that exposure to exogenous methanol affects the formation and/or persistence of the endogenous N^2^-hmdG, but not N^6^-hmdA adducts, which may have also occurred in an earlier rat study that did not report the use of unexposed controls (Lu et al., 2011). From these studies, it appears that hmDNA adducts are likely to be formed in distal tissues when formaldehyde is produced as a metabolite of chemicals such as methanol (Lu et al., 2012b) or from NNK and NDMA (Wang et al., 2007b). Thus, oral exposure to methanol, but not inhaled formaldehyde, seems to produce formaldehyde-specific adducts in distal tissues of experimental animals.

##### DNA-protein crosslinks

Several in vivo studies involving rodents and monkeys have demonstrated DPX formation following inhalation exposure to formaldehyde (see Table C-18). In rats, several short- and long-term inhalation exposures of formaldehyde have been shown to induce DPX formation in nasal passages. For example, inhalation exposure to formaldehyde induced DPX in nasal mucosa with a single 3-hour (Heck and Casanova, 1987; Casanova and Heck, 1987) or 6-hour exposure (Lam et al., 1985; Casanova et al., 1989) or 6 hours daily exposure for 2 days (Casanova-Schmitz and Heck, 1983; Casanova-Schmitz et al., 1984b).

DPX levels have been measured from the nasal lateral meatus, medial meatus, and posterior meatus (Casanova et al., 1994) or the entire nasal cavity showing a nonlinear dose-response effect at and above 0.37 mg/m^3^ dose (Casanova et al., 1989) after inhalation of ^14^C-formaldehyde. These sites have been shown to be associated with a high tumor incidence (Morgan et al., 1986b) or cellular proliferation (Monticello et al., 1989; Monticello et al., 1991) in chronic formaldehyde exposure studies in rats.

Casanova-Schmitz and Heck (1983) have reported a significant increase in DPXs in respiratory, but not olfactory mucosa, at ≥7.37 mg/m^3^ of formaldehyde exposure of rats with a linear increase in the exposure range of 2.46–36.8 mg/m^3^. The inability of this study to detect DPXs at lower levels of formaldehyde exposure is likely due to the protective mechanism of GSH, which catalyzes the oxidative metabolism of formaldehyde to formate. Lam et al. (1985) have shown that co-exposure of rats with 4.6 mg/m^3^ acrolein and 7.4 mg/m^3^ formaldehyde for 6 hours resulted in higher DPX levels in the nasal mucosa of rats compared to rats given formaldehyde alone, suggesting that GSH depletion by acrolein enhanced the macromolecule binding of formaldehyde. The same group in a different study did not detect DPX formation in the olfactory mucosa and bone marrow even at the high exposure concentration of 18.42 mg/m^3^ (Casanova-Schmitz et al., 1984b).

Casanova and Heck (1987) reported that GSH depletion caused an increase in DPX formation in the IF-DNA of the nasal mucosa of F344 rats when a dual-isotope (^3^H/^14^C) method was used. The dual isotope method distinguished between metabolic incorporation and covalent binding of formaldehyde. Formaldehyde is oxidized to formate, losing one hydrogen atom (indicated by a decrease in the ^3^H/^14^C ratio), and becomes metabolically incorporated into macromolecules. However, when GSH is not available (depleted), it leaves residual (unoxidized) formaldehyde to covalently bind to DNA, forming DPX. However, the residual formaldehyde may form adducts by reacting with deoxyribonucleosides in the DNA hydrolysates, which could also lead to an overestimation of the amount of DNA-bound formaldehyde. Casanova et al. (1989) used an improved method which is based on the determination of the total ^14^C-formaldehyde bound to DNA. This study showed that formaldehyde was exclusively bound to IF DNA, indicating the formation of DPXs. Hydrolysis of DPXs in different samples resulted in quantifiable amounts of formaldehyde to be released. DPX formation was detectable at all concentrations (0.37–12.3 mg/m^3^ for 6 hours) of formaldehyde exposure. Overall, these studies show that formaldehyde induces DPXs in nasal epithelial cells of rodents. However, there are no published rodent studies that assess DPXs beyond the nasal passages of the upper respiratory tract. Neuss et al. (2010b) did not detect a significant increase in DPX formation, as determined by the Comet assay in the bronchoalveolar lavage (BAL) cells of F344 rats exposed to up to 18.45 mg/m^3^ formaldehyde by whole-body inhalation compared to controls.

DPXs were also found in the nasal mucosa and extranasal tissues of rhesus monkeys exposed to 0.86, 2.45, or 7.36 mg/m^3^ formaldehyde 6 hours/day for 3 days (Casanova et al., 1991). These data were used as a basis for cross-species prediction of formaldehyde-induced DPXs in humans. The presence of DPXs in rhesus monkeys confirms formaldehyde‘s DNA reactivity as a general effect. Additionally, DPXs were detected in the larynx/trachea/carina (pooled sample) and in intrapulmonary airways of monkeys exposed to 2.5 or 7.4 mg/m^3^ formaldehyde. These data demonstrate direct effects of formaldehyde on DNA of tissues that correspond to observed tumor sites (e.g., nasal and nasopharynx) in humans.

Recent studies by (Lai et al., 2016) have shown that DPXs formed by endogenous formaldehyde were detectable in tissues at the portal of entry (nose) as well as at distal tissues (e.g., blood cells, and bone marrow) in rats or monkeys. However, when either species was exposed to [^13^CD_2_]-labeled formaldehyde, exogenous DPXs were detectable only in the respiratory tissues. In rats, exogenous DPXs accumulated over a 28-day period of exposure and remained up to one week after removal of exposure (see Table C-18), suggesting a much slower repair of DPXs than indicated by in vitro data from earlier studies.

Recently, another study from the same research group examined endogenous and exogenous DPX adducts in rats exposed to low levels of [^13^CD_2_]-formaldehyde (1, 30, and 300 ppb) by nose-only inhalation for 28 days (Leng et al., 2019). The authors reported detectable levels of endogenous, but not exogenous DPXs in several tissues including those in lower or upper respiratory tract (nasal epithelium, trachea, and lung), blood and bone marrow, and in tissues other than respiratory tract, bone marrow and blood cells. Thus, any exogenous formaldehyde-induced DPX adducts are below the limit of detection for exposure concentrations up to 300 ppb (Leng et al., 2019).

##### DNA-DNA crosslinks

There is limited evidence showing the formation of DNA-DNA crosslinks (DDX) induced by inhalation exposure to formaldehyde. Lu et al. (2010a) reported dG-CH2-dG crosslinks in the nasal epithelium of F344 rats exposed to 12.3 mg/m^3^ formaldehyde for 1 or 5 days (6 hours/day). However, roughly 65% of the dG-CH_2_-dG crosslinks were considered artifacts formed during sample workup and storage. Wang et al. (2007b) reported very low levels of dA-CH2-dA crosslinks of formaldehyde in rats exposed to NDMA and NNK but cautioned that these crosslinks may be generated artifactually upon DNA storage. Thus, DDX may not be a useful biomarker of formaldehyde exposure.

##### DNA SSBs by alkaline elution

Formaldehyde has been shown to induce DNA SSBs in a few studies involving mice (Wang and Liu, 2006) and rats (Sul et al., 2007; Im et al., 2006), as summarized in Tables C-18 and C-19.

Im et al. (2006) reported a dose-dependent increase in DNA damage as analyzed by the comet assay in both PBLs and livers of Sprague-Dawley rats exposed by inhalation to 6.14 and 12.3 mg/m^3^ formaldehyde. In the same strain of rats, Sul et al. (2007) also observed a dose-dependent increase in SSBs in lung epithelial cells following inhalation exposure to 0, 6.15, and 12.3 mg/m^3^ formaldehyde for 2 weeks (6 hours/day, 5 days/week). In a developmental toxicity study, pregnant mice injected i.p. with formaldehyde from gestational days 6 to 19 exhibited DNA damage in maternal as well as fetal liver at 0.2 and 1 mg/kg, respectively (Wang and Liu, 2006).

#### Cytogenetic markers of genotoxicity

##### Micronucleus

Few studies examined the effect of formaldehyde exposure on MN induction in rodents by exposing the animals by inhalation, i.p. injection, or gavage as summarized in Tables C-18 and C-19. Inhalation exposure studies in rats were negative, while studies that used formalin by gavage in mice (Ward et al., 1983) and rats (Migliore et al., 1989) were positive for MN formation. Speit and coworkers did not observe MN formation in peripheral blood cells (Speit et al., 2009) and BAL cells (Neuss et al., 2010b) of F344 rats exposed to 0, 62, 1.23, 7.38, 12.3, and 18.45 mg/m^3^ formaldehyde. However, the Neuss et al. (2010b) study did not report the use of a positive control for MN induction, while in the other two studies, the use of cyclophosphamide as a positive control did not appear to induce a high MN count and showed results within the range of control values (Speit et al., 2009; Speit et al., 2011b). (Ward et al., 1983) observed aneuploidy and structural chromosomal aberrations (e.g., breaks, exchanges, aberrant chromosomes with and without gaps) in femoral bone marrow cells of mice dosed with formalin (100 mg/kg) or methanol (1,000 mg/kg). The cytogenetic effects seen in bone marrow suggest that the formalin or methanol given by gavage was able to reach bone marrow and induce genotoxicity. Similarly, (Migliore et al., 1989) observed MN formation in the gastric epithelial cells of Sprague-Dawley rats exposed to a single dose of formalin (200 mg/kg). Lastly, Liu et al. (2017) have shown that inhalation exposure to formaldehyde in ICR mice for 20 weeks caused a significant increase in the ratio of polychromatic erythrocytes/normochromatic erythrocytes, but not micronuclei induction in bone marrow (Liu et al., 2017).

##### Sister chromatid exchanges

Few studies examined the effect of formaldehyde exposure on SCEs in mice and rats (see Tables C-18 and C-19). Two of the three studies in rats were negative for SCEs in blood cells (Speit et al., 2009; Kligerman et al., 1984), both of these studies used inhalation exposure to 18.45 mg/m^3^ formaldehyde for 6 hours/day, 5 days/week for 4 weeks.

In an inhalation study, (Brusick, 1983) exposed CD-1 mice to target concentrations of 0, 7.38, 14.76, or 30.75 mg/m^3^ formaldehyde vapors for 6 hours/day for 4–5 days. Significantly higher levels of SCEs/cell were reported in the bone marrow of female mice both at the mid and high concentrations, while the low-concentration group had levels that were not significantly different from the control group. Thus, formaldehyde exposure has provided equivocal results on the SCEs in rodents.

##### Chromosomal aberrations

Few studies reported the effect of formaldehyde inhalation on CA induction in rodents and these results were mixed (see Table C-18).

Kligerman et al. (1984) found no difference in the incidence of SCEs or CAs and mitotic index in the PBLs of male and female F344 rats exposed to formaldehyde for 5 days up to a 18.45 mg/m^3^ dose. Also, Dallas et al. (1992) reported no clastogenic effects in bone marrow of Sprague-Dawley rats exposed at the same concentration of formaldehyde for 8 weeks. However, the authors observed a modest, but statistically significant increase (1.7- to 1.8-fold) in CAs in pulmonary lavage cells at the high dose (18.45 mg/m^3^) compared to controls, but not at lower doses [0.61 and 3.7 mg/m^3^ (Dallas et al., 1992)].

Speit et al. (2009) investigated the genotoxicity of formaldehyde in peripheral blood samples of Fischer-344 rats exposed to 0 to 18.45 mg/m^3^ formaldehyde for 4 weeks (6 hours/day, 5 days/week). Compared to controls, the authors found no significant increase in genotoxicity assays such as the comet assay (with or without γ-irradiation of blood samples), the SCEs assay, and micronucleus test. Earlier studies by (Casanova-Schmitz et al., 1984b) showed that formaldehyde does not cause toxicity to bone marrow. Following formaldehyde exposure by i.p. injection in mice, data were negative for CAs in spermatocytes (Fontignie-Houbrechts, 1981; Fontignie-Houbrechts et al., 1982) and polychromatic erythrocytes (Natarajan et al., 1983), while Gomaa et al. (2012) demonstrated an increase in chromosomal aberrations in bone marrow cells of adult male albino rats exposed to formaldehyde at 0.2 mg/kg-day i.p injection for 4 weeks. Oral administration of formaldehyde to rats showed positive results for CAs in the gastric epithelial cells (Migliore et al., 1989).

Since many leukemogens initiate leukemogenesis by directly damaging the hematopoietic stem cells/hematopoietic progenitor cells (HSP/HPC), Zhao et al. (2020) examined the effect of formaldehyde exposure either in vivo or ex vivo. They exposed either BALB/c mice to 3 mg/m^3^ formaldehyde by inhalation for 2 weeks or by ex vivo to cells from bone marrow, lung, nose, and spleen with 0, 50, 100, and 400 µM formaldehyde for 1 hour. Using a myeloid progenitor colony formation (MPCF) assay, they showed that formaldehyde exposure caused a decrease in bust-forming unit-erythroid (BFU-E) and colony-forming unit-granulocyte, macrophage (CFU-GM) colonies in all of the four tissues from both in vivo and ex vivo (up to 400 μM) exposure to formaldehyde. The authors concluded that their study confirms the presence of HSP/HPC in mouse lung and nose and hypothesize that following formaldehyde-induced DNA damage at the point of entry these damaged stem cells possibly migrate to bone marrow and induce leukemia (Zhao et al., 2020). However, the formaldehyde used in this study was generated from 10% formalin which contains methanol added as a stablizer; it is likely that methanol could also contribute to the outcome, preventing attribution of the results to formaldehyde alone.

Overall, inhalation exposure to formaldehyde has produced mixed and equivocal results in rodents for cytogenetic markers of genotoxicity. Formaldehyde did not induce MN in bone marrow cells of male Sprague-Dawley rats (Dallas et al., 1992) and caused no increase in the frequency of SCEs or CAs and mitotic index in blood lymphocytes of F344 rats of either sex (Kligerman et al., 1984). However, a modest, but statistically significant, increase (1.7- to 1.8-fold) in CAs has been observed in pulmonary lavage cells of Sprague-Dawley rats after exposure to 18.45 mg/m^3^ (Dallas et al., 1992) and a significant increase in CAs in bone marrow cells of female Wistar rats exposed to 1.5 mg/m^3^ formaldehyde (Kitaeva et al., 1990); however, the latter finding involved methanol co-exposure, reducing confidence in these results. Also, formaldehyde exposure by inhalation in CD-1 mice induced SCEs in bone marrow cells at ≈15 mg/m^3^ (Brusick, 1983). Thus, some studies show that inhaled formaldehyde may be able to induce cytogenetic effects in distal tissues with repeated exposures, possibly only at very high formaldehyde concentrations.

#### Mutations

Formaldehyde exposure has been shown to induce mixed results for mutations in several test systems as summarized in Tables C-18 and C-19. The dominant lethal mutation test has been performed using mice and rats, where males were exposed to formaldehyde or formalin vapors by inhalation or i.p. injection, mated with females, and where mutations were then scored in the offspring. In two of these studies, formaldehyde injected i.p. to CD-1 mice was negative for dominant lethal mutations (Epstein and Shafner, 1968; Epstein et al., 1972), while another study which used a higher dose (50 mg/kg) of formaldehyde showed weakly positive results (Fontignie-,Houbrechts, 1981). Specific pathogen-free ICR mice exposed to inhaled formaldehyde were positive for dominant lethal mutations (Liu et al., 2009b). In this study, mutation rates were dose dependent and mainly inherited from the paternal germ line.

Recio et al. (1992) demonstrated point mutations in the GC base pairs of the p53 tumor suppressor gene in 45% (5 out of 11) of the primary nasal squamous cell carcinomas (SCCs) from F344 rats that were chronically (2 years) exposed to 18.45 mg/m^3^ formaldehyde. Samples from this study were further analyzed by Wolf et al. (1995) who demonstrated the presence of the p53 tumor suppressor protein which correlated with the proliferating cell nuclear antigen (PCNA) but not TGF-alpha in the nasal SCCs. However, Meng et al. (2010) failed to detect p53 mutations in the nasal mucosa of rats exposed to 0.86 to 18.42 mg/m^3^ formaldehyde for 13 weeks. It is likely that the duration of exposure is important for the mutations to occur in these studies. In summary, formaldehyde produced mixed results in the DLM test. Short-term (13-week) exposure of rats to formaldehyde did not produce detectable mutations in the p53 tumor suppressor gene or Ha-ras oncogene; however, a chronic 2-year study resulted in SCC formation and mutations in the GC base pairs of the p53 gene in rats.

Table C-18 Summary of in vivo genotoxicity studies of formaldehyde inhalation exposure in experimental animals

Test system | Concentration^a^ | Results^b^ | Comments | Reference
Mutation
Evaluations specific to genotoxicity in the upper or lower respiratory tract
Rats/F344, nasal SCCs | 18.45 mg/m^3^; HCHO from PFA^c^ | + | Inhalation, 6 hrs/d, 5 d/wk, 2 years | (Recio et al., 1992)
Rats/F344, nasal SCCs | 18.45 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d, 5 d/wk, 2 years | (Wolf et al., 1995)
Rats/F344, nasal mucosa | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, 5 d/wk,13 wks; Cell proliferation showed a conc.-dependent ↑; significant at 12.3 and 18.45 mg/m^3^ exposures | (Meng et al., 2010)
Evaluations specific to genotoxicity to systems other than the respiratory tract, bone marrow, or blood cells
Rats/Strain not specified - dominant lethal test | 1.47 mg/m^3^; HCHO (not specified) | (+) | Inhalation, 4 hrs/d for 4 wks | (Kitaeva et al., 1990)
Mice/ICR, specific pathogen-free dominant lethal test | 200 mg/m^3^; Formalin (37% HCHO w/w aq.sol.) | + | Whole-body inhalation exposure of ♂ mice for 2 hrs; 6 wks postexposure ♂ mated to ♀ at 1:1; | (Liu et al., 2009b)
DNA-protein crosslinks
Evaluations specific to genotoxicity in the upper or lower respiratory tract
Monkey/Rhesus nasal turbinates | 0.86 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs; the LEC ↑ with the ↑ in distance from the portal of entry; DPX levels show conc.-dependent ↑ from 0.86–7.4 mg/m^3^, in the order of middle turbinates > lateral wall/septum, nasopharynx > larynx/trachea/carina. | (Casanova et al., 1991)
Monkey/Rhesus nasal, larynx, trachea, & carina | 2.5 mg/m^3^; HCHO from PFA | + | | (Casanova et al., 1991)
Monkey/Rhesus maxillary sinuses, lungs | 7.4 mg/m^3^; HCHO from PFA | + | | (Casanova et al., 1991)
Monkeys/Cynomolgus nose | 7.4 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d, for 2 d | (Lai et al., 2016)
Rats/F344 nasal mucosa | 0.37 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs; nonlinear conc.-dependent ↑ in DPX level between 0.37 to 12.1 mg/m^3^ | (Casanova et al., 1989)
Rats/F344 nasal mucosa | 0.86 mg/m^3^; HCHO from PFA | + | Inhalation 6 hrs/d, 5 d/wk, 11 wk + 4 d + 3 hrs (preexposed); or 3 hrs only (naïve); ↑cell proliferation ≥ 7.48 mg/m^3^ | (Casanova et al., 1994)
Rats/F344 nasal mucosa | 2.5 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d, for 2 d; cytotoxicity ≥ 12.3 mg/m^3^ | (Casanova-Schmitz et al., 1984a)
Rats/F344 nasal mucosa | 2.5 mg/m^3^; HCHO from PFA | + | Inhalation, 3 hrs/d, for 2 d | (Casanova and Heck, 1987)
Rats/F344 nasal mucosa | 2.5 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d; for 7 or 28 d | (Lai et al., 2016)
Rats/F344 nasal mucosa | 7.4 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/day, for 2 d | (Casanova-Schmitz and Heck, 1983)^b^
Rats/F344 nasal mucosa | 7.4 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs; co-exposure to 2 ppm acrolein caused a significant ↑ in toxicity and DPX formation | (Lam et al., 1985)
Rats/F344 nasal mucosa | 18.45 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d; for 1, 2, and 4 d | (Lai et al., 2016)
Rats/F344 olfactory mucosa | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, for 2 d | (Casanova-Schmitz et al., 1984a)
Rats/F344 nasal mucosa | 36.9 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, for 2 d | (Casanova-Schmitz and Heck, 1983)^b^
Rats/F344, nasal epithelium, trachea, lung | 0.0012, 0.0369, 0.369 mg/m^3^ [^13^CD_2_]-HCHO | - | Inhalation, nose-only, 6 hrs/d, 28 d | (Leng et al., 2019)
Rats/F344 BAL cells | 18.45 mg/m^3^; HCHO from formalin vapors | − | Inhalation, 6 hrs/d, 5 d/wk, for 4 wks | (Neuss et al., 2010a)
Mice/BalbC lung | 3.0 mg/m^3^; HCHO vapor from 10% formalin | − | Inhalation, nose-only; 8 hrs/d for 7 d; | (Ye et al., 2013)
Evaluations specific to genotoxicity in cells of the blood and bone marrow
Monkeys/Cynomolgus bone marrow, PBMC | 7.4 mg/m^3^; HCHO from PFA | - | Inhalation, 6 hrs/d, for 2 d | (Lai et al., 2016)
Rats/F344 bone marrow | 12.43 mg/m^3^; HCHO from PFA | − | Inhalation, 3 hrs/d, for 2 d | (Casanova and Heck, 1987)
Rats/F344 bone marrow | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, for 2 d | (Casanova-Schmitz et al., 1984a)
Rats/F344 bone marrow, PBMC | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d; for 1, 2, and 4 d | (Lai et al., 2016)
Rats/F344, bone marrow, PB MC | 0.0012, 0.0369, 0.369 mg/m^3^ [^13^CD_2_]-HCHO | - | Inhalation, nose-only, 6 hrs/d, 28 d | (Leng et al., 2019)
Rats/F344 peripheral blood | 18.45 mg/m^3^; HCHO from formalin vapors | − | Inhalation, 6 hrs/d, 5 d/wk, for 4 wks | (Speit et al., 2009)
Mice/BalbC bone marrow | 1.0 mg/m^3^; HCHO vapor from 10% formalin | + | Inhalation, nose-only; 8 hrs/d for 7 d; dose-dependent ↑ in DPX levels | (Ye et al., 2013)
Mice/BalbC PBM cells | 3.0 mg/m^3^; HCHO vapor from 10% formalin | + | Inhalation, nose-only; 8 hrs/d for 7 d; dose-dependent ↑ in DPX levels | (Ye et al., 2013)
Evaluations specific to genotoxicity in systems other than the respiratory tract, bone marrow or blood cells
Monkeys/Cynomolgus liver | 7.4 smg/m^3^; HCHO from PFA | - | Inhalation, 6 hrs/, for 2 d | (Lai et al., 2016)
Rats/F344, olfactory bulbs, liver, hippo campus, cerebellum | 0.0012, 0.0369, 0.369 mg/m^3^ [^13^CD_2_]-HCHO | - | Inhalation, nose-only, 6 hrs/d, 28 d | (Leng et al., 2019)
Mice/Kunming kidney and testes | 0.5 mg/m^3^; HCHO vapor from 10% formalin | + | Inhalation, 72 hrs continuous exposure | (Peng et al., 2006)
Mice/Kunming liver | 1.0 mg/m^3^; HCHO vapor from 10% formalin | + | Inhalation, 72 hrs continuous exposure | (Zhao et al., 2009; Peng et al., 2006)
Mice/BalbC spleen, testes | 1.0 mg/m^3^; HCHO vapor from 10% formalin | + | Inhalation, nose-only; 8 hrs/d for 7 d; dose-dependent ↑ in DPX levels | (Ye et al., 2013)
DNA adducts
Evaluations specific to genotoxicity in the upper or lower respiratory tract
Monkey/Cynomologus maxilloturninate | 2.33 mg/m^3^; HCHO (not specified) | + | Inhalation, 6 hrs/d, for 2 d; conc.-dependent ↑ in exogenous adducts | (Moeller et al., 2011)
Monkeys/Cynomolgus - nasal dorsal mucosa, nasopharynx, nasal septum, nasal posterior maxillary | 7.5 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d, for 2 d | (Yu et al., 2015b)
Monkeys/Cynomolgus - trachea carina, trachea proximal | 7.5 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, for 2 d | (Yu et al., 2015b)
Rats/F344 nasal epithelium | 0.86 mg/m^3^; HCHO from PFA | + | Inhalation, for 6 hrs; conc.-dependent ↑ in exogenous adducts | (Lu et al., 2011)
Rats/F344 nasal epithelium | 2.46 mg/m^3^; HCHO from PFA | + | Inhalation, 6 hrs/d, for 7, 14, 21, or 28 d; recovery for 6, 24, 72, or 168 hrs; exposure-dependent ↑ in hmdG mono adducts | (Yu et al., 2015b)
Rats/F344 -nasal epithelium | 12.3 mg/m^3^; 20% HCHO in water | + | Inhalation, 1 and 5 d; exposure-dependent ↑ in exogenous hmdG adduct and dG-dG crosslinks | (Lu et al., 2010a)
Rats/F344 lung | 12.3 mg/m^3^; HCHO from PFA | − | Inhalation, 1 and 5 d | (Lu et al., 2010a)
Rats/F344, nasal epithelium, trachea, lung | 0.0012, 0.0369, 0.369 mg/m^3^ [^13^CD_2_]-HCHO | - | Inhalation, nose-only, 6 hrs/d, 28 d | (Leng et al., 2019)
Evaluations specific to genotoxicity in cells of the blood and bone marrow
Monkey/Cynomologus bone marrow | 2.33 mg/m^3^; HCHO (not specified) | − | Inhalation, 6 hrs/d, for 2 d | (Moeller et al., 2011)
Monkeys/Cynomolgus bone marrow, white blood cells | 7.5 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, for 2 d | (Yu et al., 2015b)
Rats/F344 white blood cells and bone marrow cells | 12.3 mg/m^3^; HCHO from PFA | − | Inhalation, 1 and 5 d | (Lu et al., 2010a)
Rats/F344, bone marrow, PB MC | 0.0012, 0.0369, 0.369 mg/m^3^ [^13^CD_2_]-HCHO | - | Inhalation, nose-only, 6 hrs/d, 28 d | (Leng et al., 2019)
Evaluations specific to genotoxicity in systems other than the respiratory tract, bone marrow or blood cells
Rats/F344 thymus, lymph nodes, trachea, lung, spleen, kidney, liver, brain | 2.46 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, for 28 d | (Yu et al., 2015b)
Rats/F344 liver, spleen, thymus | 12.3 mg/m^3^; HCHO from PFA | − | Inhalation, 1 and 5 d | (Lu et al., 2010a)
Rats/F344, olfactory bulbs, liver, hippo campus, cerebellum | 0.0012, 0.0369, 0.369 mg/m^3^ [^13^CD_2_]-HCHO | - | Inhalation, nose-only, 6 h/d, 28 d | (Leng et al., 2019)
Chromosomal aberrations
Evaluations specific to genotoxicity in the upper or lower respiratory tract
Rats/SD Pulmonary lavage cells | 18.45 mg/m^3^; HCHO from PFA | + | Inhalation, whole body; 6 hrs/d, 1 or 8 wks | (Dallas et al., 1992)
Evaluations specific to genotoxicity in cells of the blood and bone marrow
Rats/Wistar Bone marrow | 0.49 mg/m^3^; HCHO (not specified) | + | Inhalation, 4 hrs/d, 4 mos | (Kitaeva et al., 1990)
Rats/SD Bone marrow | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, whole body; 6 hrs/d, 1 or 8 wks | (Dallas et al., 1992)
Rats/F344 Peripheral blood cells | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, 5 d/wk, for 4 wks | (Speit et al., 2009)
Rats/F344 Lymphocytes | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, 5 d; no significant dose-related effect on mitotic activity | (Kligerman et al., 1984)
Mice/CD-1, male & female, Bone marrow cells | 30.75 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, 4–5 d | (Brusick, 1983)
Mice/BALB/c, bone marrow – hematopoietic stem and progenitor cells | 3 mg/m^3^, HCHO from 10% formalin | + | Inhalation, 8 hrs/d, 5 d/wk, 2 wks | (Zhao et al., 2020)
Micronucleus
Evaluations specific to genotoxicity in the upper or lower respiratory tract
Rats/F344 BAL cells | 18.45 mg/m^3^; HCHO from formalin vapors | − | Inhalation, 6 hrs/d, 5 d/wk, for 4 wks; positive control was not used for the assay | (Neuss et al., 2010a)
Evaluations specific to genotoxicity in cells of the blood and bone marrow
Rats/Outbred white polychromatophylic erythrocytes (bone marrow) | 12.8 mg/m^3^, commercial formaldehyde | + | Inhalation; whole-body exposure; 4 hrs/d, 5 d/wk | (Katsnelson et al., 2013)
Rats/F344 -peripheral blood | 18.45 mg/m^3^; HCHO from formalin vapors | − | Inhalation, 6 hrs/day, 5 days/wk, for 4 wks | (Speit et al., 2009)
Mice/male ICR bone marrow cells | 20 mg/m^3^ 36.5%–38% HCHO in water (formalin) | + | Inhalation, 2 hrs/d for 15 d | (Yu et al., 2014a)
Mice/ICR, bone marrow cells | 1, 10 mg/m^3^, HCHO source not reported | - | Inhalation, 2 hrs/d, 20 wks; micronucleus | (Liu et al., 2017)
Single strand breaks
Evaluations specific to genotoxicity in the upper or lower respiratory tract
Rats/SD lung epithelial cells | 6.14 mg/m^3^; HCHO (commercial) | + | Inhalation, 6 hrs/d, 5 d/wk for 2 wks; ↑ cytotoxicity (lipid peroxidation & protein carbonyl oxidation) observed at 18.42 mg/m^3^ | (Sul et al., 2007)
Evaluations specific to genotoxicity in blood cells
Rats/SD, PBLs | 6.14 mg/m^3^; HCHO (commercial) | + | Inhalation, 5 d/wk for 2 wks | (Im et al., 2006)
Evaluations specific to genotoxicity in systems other than the respiratory tract, bone marrow or blood cells
Rats/SD, liver | 6.14 mg/m^3^; HCHO (commercial) | + | Inhalation, 5 d/wk for 2 wks | (Im et al., 2006)
Sister chromatid exchanges
Evaluations specific to genotoxicity in cells of the blood and bone marrow
Rats/F344 Lymphocyte | 18.45 mg/m^3^; HCHO from PFA | − | Inhalation, 6 hrs/d, 5 d; no significant dose-related effect on mitotic activity | (Kligerman et al., 1984)
Rats/F344 Peripheral blood cells | 18.45 mg/m^3^; Formalin vapors | − | Inhalation, 6 hrs/d 5 d/wk, for 4 wks | (Speit et al., 2009)
Mice/CD-1, male & female Bone marrow cells | 14.76 mg/m^3^; HCHO from PFA | −, + | Inhalation, 6 hrs/d, 5 d; ♂ mice: −ve; ♀ mice: +ve; conc.-dependent ↑ in SCEs | (Brusick, 1983)

Gray shading indicates experiments examining tissues or cells outside of the upper respiratory tract that are assumed to have included co-exposure to methanol, and are thus may be less reliable.

a Lowest effective concentration (LEC) for positive results or highest ineffective concentration tested (HIC) for negative or equivocal results.

b + = positive; − = negative; (+), equivocal.

c Thermal depolymerization of paraformaldehyde (PFA) or freshly prepared formalin (no methanol) are the preferred test article methods. Generation of formaldehyde from formalin, uncharacterized aqueous solutions (noted as not specified), or an unspecified source (also noted as not specified) is assumed to involve co-exposure to methanol, and the evidence is less reliable.

HCHO, formaldehyde; PFA, paraformaldehyde; hmDNA, hydroxymethylDNA; SCE, sister chromatid exchange; SCC, squamous cell carcinoma; hmdA, hydroxymethyl deoxyadenosine; hmdG, hydroxymethyl deoxyguanosine; MN, micronucleus.

Part of the data adapted from NTP (2010).

Table C-19 Summary of in vivo genotoxicity studies of formaldehyde exposure by intraperitoneal and oral routes of exposure in experimental animals

Test system | Concentration^a^ | Results^b^ | Comments | Reference
Mutation
Rats/Albino Spermatocyte; DLM | 0.125 mg/kg; test article: [underlined: 37% HCHO (+ 10% methanol)] | + | i.p., ♂ given 5 daily doses and mated to ♀; dose-dependent ↑ in DLM index; effects greater with shorter time gap postexposure | (Odeigah, 1997)
Mice/CD-1 DLM test | 20 mg/kg HCHO; test article: [underlined: Not Specified] | − | i.p. injection to ♂; mated to ♀ and autopsied 13 d past mid-wk of mating | (Epstein and Shafner, 1968)
DNA-protein crosslinks
Rats/F344 tracheal implants | 0.01% HCHO in PBS; test article: [underlined: Not Specified] | + | instillation, twice weekly for 2, 4, or 8 wks | (Cosma et al., 1988)
Mice/NS liver (Fetal) [Chinese lang-English Abstract] | 0.2 mg/kg; test article: [underlined: HCHO (not specified)] | + | i.p. injection to pregnant mice from GD 6 to 19 | (Wang and Liu, 2006)
Mice/NS Liver (maternal) [Chinese lang-English Abstract] | 20 mg/kg; test article: [underlined: HCHO (not specified)] | − | i.p. injection to pregnant mice from GD 6 to 19 | (Wang and Liu, 2006)
Chromosomal aberrations
Mice/CBA femoral polychromatic erythrocytes | 25 mg/kg; test article: HCHO (PFA in water) | − | i.p. injections (2) within 24 hr interval; cells sampled 16 and 40 hrs post 2nd injection | (Natarajan et al., 1983)
Mice/Q strain Spermatocytes | 50 mg/kg; test article: [underlined: HCHO (35% sol.)] | − | i.p. injection, single | (Fontignie-Houbrechts, 1981)
Mice/Q strain Spermatogonia | 30 mg/kg; test article: [underlined: HCHO (commercial)] | − | i.p. injection, 35% HCHO solution + 90 mg/kg H_2_O_2_ | (Fontignie-Houbrechts et al., 1982)
Rats/SD gastric epithelial cells (stomach, duodenum, ileum, colon) | 200 mg/kg; test article: HCHO (in water) | + | p.o. gavage, 16, 24, or 30 hrs; time-dependent ↑ in CA in all tissues; toxic at 30 hrs; no significant change in mitotic index | (Migliore et al., 1989)
Mice/B6C3F1-bone marrow | 100 mg/kg; test article: [underlined: formalin]; or 1,000 mg/kg methanol | + | Gavage, single exposure; HCHO and methanol showed 21– and 15–fold increase compared to controls, respectively | (Ward et al., 1983)
Rats (male albino), bone marrow cells | 0.2 mg/kg-day; test article: HCHO (source not specified) | + | i.p injection, single injection for 4 wks | (Gomaa et al., 2012)
Micronucleus
Mice/CBA femoral polychromatic erythrocyte and spleen cell | 25 mg/kg; test article: HCHO (PFA in water) | − | i.p. injections (two) of HCHO solution within 24 hr interval; cells sampled 16 and 40 hrs post 2nd injection | (Natarajan et al., 1983)
Mice/NMRI bone marrow | 30 mg/kg; test article: [underlined: HCHO (commercial)] | − | i.p. injection, single | (Gocke et al., 1981)
Mice/CD-1 reticulocytes | 30 mg/kg; test article: [underlined: HCHO (35%)] | − | i.v. 2 injections; sampled 24, 48, or 72 hrs after exposure | (Morita et al., 1997)
Mice/CD-1 bone marrow or peripheral blood | 200 mg/kg; test article: [underlined: 35% HCHO] | − | Gavage twice (bone marrow) or once (peripheral blood); all mice killed at 300 mg/kg dose | (Morita et al., 1997)
Rats/SD gastric epithelial cells (stomach, duodenum, ileum, colon) | 200 mg/kg; test article: HCHO (in water) | + | p.o. gavage, 16, 24, or 30 hrs; time-dependent ↑ in MN in all tissues; toxic at 30 hrs; no significant change in mitotic index | (Migliore et al., 1989)

a Lowest effective concentration (LEC) for positive results or highest ineffective concentration (HIC) tested for negative or equivocal results.

b + = positive; − = negative; (+), equivocal.

c Thermal depolymerization of paraformaldehyde (PFA) or freshly prepared formalin (no methanol) are the preferred test article methods. Generation of formaldehyde from formalin, uncharacterized aqueous solutions (noted as not specified), or an unspecified source (also noted as not specified) is assumed to involve co-exposure to methanol, and the evidence is less reliable.

HCHO, formaldehyde; PFA, paraformaldehyde; DLM, dominant lethal mutation; i.p., intra peritoneal; i.v., intra venous; GD, gestation day; MN, micronucleus.

Part of the data adapted from NTP (2010).

#### Summary of in vivo genotoxicity studies of formaldehyde by routes of exposure in experimental animals

Formaldehyde reacts with cellular macromolecules at the portal of entry causing genotoxicity. Genotoxicity of inhaled formaldehyde involves direct interaction with DNA inducing DNA-protein crosslinks and/or hydroxymethylDNA adducts or DNA mono adducts, single strand breaks, micronuclei, and chromosomal aberrations in nasal passages of experimental animals. DPX are formed predominantly by crosslinking of the epsilon-amino groups of lysine and the exocyclic amino groups of DNA, especially at the N-terminus of histone. Due to the differences in the anatomy of nasal passages and breathing patterns of rats and monkeys, the location of DPX formation differs. Over a range of 0.86 to 7.37 mg/m^3^, formaldehyde-induced DPX levels showed a concentration-dependent increase in the monkey respiratory tract in the order of middle turbinates > anterior lateral wall/septum > maxillary sinuses and lungs. Thus, the lowest effective concentration (LEC) was higher with increased anatomical distance from the portal of entry. Furthermore, these anatomical sites are known to be associated with formaldehyde-induced proliferative response in monkeys. In rats, DPX formation showed concentration dependence between 0.37–12.1 mg/m^3^ formaldehyde, which was nonlinear with a sharp increase above 4.9 mg/m^3^. With exposures up to 28 days, DPXs were shown to accumulate and persisted for an additional 7 days at a concentration of 2.5 mg/m^3^. In addition, DPX formation was six-fold higher in the lateral meatus compared to the medial and posterior meatus, corresponding, respectively, to high and low tumor incidence sites in rats. DPXs were not detected in olfactory mucosa, bronchoalveolar lavage (BAL) cells of rats or in lungs of mice exposed to formaldehyde. DPXs (from exogenous formaldehyde) also were not detected in bone marrow and peripheral blood monocyte cells (rats and monkeys) and liver (monkeys) following inhalation exposure. Since DPXs are likely to induce replication errors, they have been considered to be a marker of mutagenicity. The repair of DPX in eukaryotes appears to depend on the dose and duration of formaldehyde exposure. The overall evidence indicates that the DPXs are markers of exposure as well as genotoxic endpoints.

HydroxymethylDNA adducts in experimental animals can result from DNA reacting with endogenously-produced or exogenous formaldehyde. Mono adducts formed from endogenous formaldehyde (produced during normal cellular metabolism) are distinguished from those formed by exogenous exposure using stable isotope (^13^C)-labeled formaldehyde coupled with sensitive MS techniques. Inhaled formaldehyde induces N2-hmdG adducts in the nasal epithelium of F344 rats, but not in distal tissues, and the adduct levels are associated with concentration and duration of exposure. In rhesus monkeys, formaldehyde induces N2-hmdG adducts in the maxilloturbinates, and the mono adduct levels are associated with the exposure concentration of formaldehyde. Endogenous N2-hmdG mono adducts and dG-dG crosslinks are also detected in rats and monkeys, but in all experimental animals exposed exogenously to formaldehyde by inhalation, N2-hmdG adducts were only elevated in nasal passages, not in tissues beyond the portal of entry. However, formaldehyde-specific hmDNA adducts have been detected in rodent tissues distal to the portal of entry when the animals were exposed to methanol or nitrosamines, which are known to release formaldehyde as a metabolic intermediate in vivo. These studies suggest a lack of transport of formaldehyde beyond the portal of entry when given by inhalation in animals. Although the hmDNA adducts are considered to be genotoxic endpoints of formaldehyde exposure, their mutagenicity has not been established.

There is limited evidence about mutagenicity of formaldehyde in experimental animals. Formaldehyde did not induce mutations in the nasal mucosa of rats with inhalation exposure to 18.5 mg/m^3^ for 13 weeks, but there are no available studies involving longer periods of exposure (see Table C-18). However, formaldehyde inhalation exposure caused other genotoxic endpoints, including chromosomal aberrations and single strand breaks but not micronuclei in cells of the respiratory system (Table C-18).

Twelve out of 17 that analyzed formaldehyde-induced genotoxic endpoints in bone marrow or blood cells were negative. Conflicting results have been obtained in terms of the source of formaldehyde. Formaldehyde derived from paraformaldehyde or commercial formalin was negative for DPX formation in bone marrow and peripheral blood cells, although one recent study, which used 10% formalin as a source of formaldehyde, induced DPX formation in bone marrow and peripheral blood mononuclear cells. Formaldehyde did not induce hmDNA adducts in the bone marrow of monkeys and rats, suggesting that inhaled exogenous formaldehyde may not be transported to the tissues distal to the portal of entry. Formaldehyde failed to induce CAs in 4/5 studies in the bone marrow or peripheral blood cells of rats and mice (see Tables C-18 and C-19), although one study detected CAs in bone marrow of rats. Limited available evidence shows that inhaled formaldehyde did not induce micronuclei in the peripheral blood cells of rats, but was positive for inducing SSBs in peripheral blood and bone marrow cells and produced mixed results on SCE formation. The above studies clearly indicate the complexity of data analyses with contradicting results even when using the same assay system, type of exposure, and/or methodology.

Formaldehyde produced mixed results in tissues other than the respiratory and hematopoietic systems (see Tables C-18 and C-19). Three studies demonstrated DPX formation in mouse kidney, testes, liver and spleen when 10% formalin was used as a source of formaldehyde. Inhaled formaldehyde did not induce hmDNA adducts in the liver, spleen, and thymus of rats, but SSBs were detectable in the liver of rats following inhalation exposure.

Several studies evaluated the genotoxicity and mutagenicity of formaldehyde by routes other than inhalation exposure and reported mixed results (see Table C-19), suggesting that formaldehyde induced genotoxicity might depend on the route of exposure and formulation of formaldehyde administered.

### C.3.6 Genotoxic Endpoints in Humans

A large set of research studies in several countries, involving different exposure settings, found that exposure to formaldehyde is associated with damage or changes to human DNA that inform mechanisms of carcinogenesis. These studies have observed increased levels of DNA damage, DNA-protein crosslinks, and chromosomal breaks in buccal and nasal epithelial cells, and peripheral blood lymphocytes (PBLs). Chromosomal damage, manifested as an increased frequency of different types of chromosomal aberrations, has been reported. It has been shown that an increased frequency of chromosomal aberrations and micronuclei are associated with increased cancer mortality, and these endpoints are considered by EPA to be highly relevant to the assessment of genotoxicity in humans (U.S. EPA, 2005; Bonassi et al., 2004b; Bonassi et al., 2007; Bonassi et al., 2008; Bonassi et al., 2011). Single strand breaks in DNA, indicating genetic instability also are considered by EPA to be highly relevant to the assessment of genotoxicity for humans. However, an increased level of sister chromatid exchange in peripheral lymphocytes has not been found to be associated with cancer mortality in a large collaborative evaluation (Bonassi et al., 2004a). Although sister chromatid exchange is an indication of genotoxicity, this endpoint is considered to be less relevant as a predictor of cancer risk. The studies that reported SCE results were evaluated and are summarized in tables but are not synthesized because of the large amount of evidence for other genotoxicity endpoints.

EPA evaluated the studies, focusing on study design, comparison groups, assessment of exposure and cytogenetic endpoints, and analytic methods. As discussed in this synthesis, although the entire set of studies contributed to the assessment, those with the stronger study designs and methods, and which provided adequate details, were given more weight. Most of the studies reporting on measures of genotoxicity did not describe the details of population selection, recruitment, and participation, which makes it difficult to evaluate potential selection bias. However, most did report details on the population, and since knowledge of a person’s status regarding these endpoints would not be a factor in his or her decision to participate, the population selection reporting deficiency is likely not a serious limitation.

#### Chromosomal Aberrations in Peripheral Blood Lymphocytes

A total of 16 studies were available that evaluated chromosomal aberrations in peripheral blood lymphocytes (PBLs) or less differentiated subsets among individuals in a variety of exposure settings, including students in anatomy and embalming courses, workers in industrial settings, and workers in pathology laboratories (Table C-20). Average formaldehyde concentrations in these occupational settings generally were above 0.1 mg/m^3^, although two studies evaluated chromosomal aberrations among groups exposed to lower average concentrations (Santovito et al., 2011; Pala et al., 2008). Study results were heterogeneous, and the studies were variable in their study designs and reporting detail. Several did not state whether sample analysis was blinded with respect to exposure status, did not provide demographic information on exposed and referent groups to support assertions of similarity, had extremely small sample sizes (N <15), or incubated cells for longer than 48–50 hours (thus not restricting to M_1_ metaphases, and/ or did not describe their approach to data analysis: (Vasudeva and Anand, 1996; Vargová et al., 1992; Thomson et al., 1984; Suskov and Sazonova, 1982; Lazutka et al., 1999; Kitaeva et al., 1996; He et al., 1998; Gomaa et al., 2012; Fleig et al., 1982). Nine publications for 8 occupational groups provided detailed descriptions of study methods and important attributes of the exposed and referent groups (Zhang et al., 2010; Santovito et al., 2011; Santovito et al., 2014; Pala et al., 2008; Musak et al., 2013; Lan et al., 2015; Jakab et al., 2010; Costa et al., 2015; Bauchinger and Schmid, 1985).

Formaldehyde was associated with a higher prevalence of chromosomal aberrations among workers in pathology laboratories (Santovito et al., 2011; Musak et al., 2013; Jakab et al., 2010; Costa et al., 2015); these effects included chromatid-type aberrations (Jakab et al., 2010; Costa et al., 2015), chromosome-type aberrations (Musak et al., 2013; Costa et al., 2015), chromosomal exchange (Musak et al., 2013), and premature centromere division (Jakab et al., 2010). Costa et al. (2015) also reported an increase in aneuploidies and in the number of aberrant and multiaberrant cells. In one study of paper makers, formaldehyde exposure was associated with dicentrics and centric rings (Bauchinger and Schmid, 1985). Average 8-hour TWA formaldehyde concentrations of 0.32, 0.47, and 0.9 mg/m^3^ were associated with a 1.7–1.9-fold increase in total chromosomal aberrations among exposed groups (Musak et al., 2013; Jakab et al., 2010; Costa et al., 2015). An increased mean number of chromosomal aberrations per cell was significantly associated with an 8-hour TWA concentration of 0.07 mg/m^3^ among pathologists compared to referent hospital workers exposed to 0.04 mg/m^3^ by Santovito et al. (2011). One well-conducted study did not observe associations (Pala et al., 2008), possibly because the group of laboratory workers was exposed to very low formaldehyde concentrations (75% of workers at < 0.026 mg/m^3^). Another study in nurses found no differences with their referent group, although this group likely experienced a wide variation in the intensity of their formaldehyde exposure, and no formaldehyde measurements were conducted (Santovito et al., 2014). An increased frequency of chromosomal aberrations or aberrant cells was also found in a few studies that incubated cell cultures for a longer period (72 hours) (Lazutka et al., 1999; Kitaeva et al., 1996; Gomaa et al., 2012), but not by all (Vasudeva and Anand, 1996; Fleig et al., 1982). Incubation times longer than required to achieve first generation metaphase would be expected to result in greater heterogeneity in the aberration frequencies detected.

Zhang et al. (2010), using fluorescence in situ hybridization techniques, observed an increased level of chromosome aneuploidy (monosomy 7 and trisomy 8) in cultured CFU-GM colony cells in a small group of highly exposed formaldehyde-melamine production workers (n = 10) compared to a referent group matched by age and gender (n = 12). Although only a small number of workers were evaluated, this report provided complete details on study design, participation, population characteristics, exposure measurements, cytogenetic analyses, and data analysis and results. Subsequently, a larger group of the same cohort (n = 29 exposed, n = 23 referent) were included in a chromosome-wide evaluation of aneuploidy, again using cultured CFU-GM colony cells (Lan et al., 2015). An elevated risk ratio for monosomy, trisomy, and tetrasomy was found in several chromosomes, including chromosomes 5 and 7, a finding that was predicted a priori. In addition, investigators reported an increased frequency of structural chromosome aberrations in chromosome 5 (IRR 4.15, 95% CI 1.20–14.35). Gentry et al. (2013) reported on analyses using data on the cohort studied by Zhang et al. (2010) and noted that few of the DNA analyses scored 150 or more cells per individual as specified by the study protocol. Although the pilot study methods were criticized for not adhering to the assay protocol (Gentry et al., 2013), a clarification of the assay protocol was provided by the investigators with a description of how the study adhered to it (Rothman et al., 2017). The criticism by Gentry et al. (2013) applied to both the exposed and unexposed groups; thus, no bias should have occurred. Analyzing fewer cells per individual may have increased the variability in the prevalence estimates of aneuploidy, which may have attenuated the measures of association. Although the chromosome anomalies may have arisen either in vivo or during the in vitro cell culture period (Gentry et al., 2013), there was a significant increase in the exposed workers compared to the referent group, indicating a formaldehyde-associated tendency toward aneuploidy or other chromosomal aberrations. Median formaldehyde concentrations measured in the exposed and referent groups were 1.7 mg/m^3^ and 0.032 mg/m^3^, respectively. Personal exposure monitoring was conducted for several other chemical exposures, including chloroform, methylene chloride, tetrachloroethylene, trichloroethylene, benzene, or other hydrocarbons, which were not detected. Statistical models were adjusted for potential confounders including age, gender, recent infection, body mass index, and current tobacco, alcohol, and medication use.

The differences in lymphocyte subset levels between exposed and unexposed workers reported by Zhang et al. (2010) were challenged by Mundt et al. (2017) in a reanalysis that did not find evidence of an exposure-response trend within the exposed group, although the difference between unexposed and exposed subjects was reconfirmed. Rothman et al. (2017) also responded to the critique by Mundt et al. (2017) explaining that the exposure levels in the exposed group were relatively homogenous and the study was not designed to provide a range of exposures wide enough to evaluate exposure-response relationships given the expected effect size and sample size in the study. Overall, the evidence from the set of studies in which there is higher confidence is consistent with the finding that formaldehyde exposure is associated with chromosomal aberrations in PBLs.

#### Micronuclei

An increase in micronuclei in buccal mucosa, nasal mucosal cells and peripheral blood lymphocytes (PBLs) was associated with formaldehyde exposure in a large number of studies (see Table C-20). Micronuclei were reported in a diverse set of exposed populations including plywood production workers, formaldehyde production and other chemical workers, pathologists and other laboratory workers, and anatomy and mortuary lab students, and were observed at average concentrations of 0.1 mg/m^3^ (Wang et al., 2019; Ballarin et al., 1992), 0.2 mg/m^3^ (Ladeira et al., 2011; Costa et al., 2019), and 0.5 mg/m^3^ (Ying et al., 1997; Costa et al., 2008; Costa et al., 2011; Costa et al., 2013). Micronuclei in peripheral lymphocytes and exfoliated cells are considered biomarkers of genotoxic events and chromosomal instability, including errors in DNA repair mechanisms, dysfunction or lack of telomeres, and other failures during DNA replication and repair processes (Bonassi et al., 2011). Micronuclei in PBL is a validated predictor of cancer risk in epidemiology studies (Bonassi et al., 2007). Studies of exposure to formaldehyde over a short duration found no changes in micronucleus frequency in nasal mucosal cells (Zeller et al., 2011), buccal mucosal cells after a 4-hour exposure for 10 days (Speit et al., 2007a) or PBLs with an 8-hour cross-shift change (Lin et al., 2013).

Measurements in exfoliated buccal cells (EBC) revealed a consistently increased frequency of micronuclei or binucleated cells among exposed individuals (Ying et al., 1997; Viegas et al., 2010; Titenko-Holland et al., 1996; Suruda et al., 1993; Peteffi et al., 2015; Ladeira et al., 2011; Costa et al., 2019; Burgaz et al., 2002; Aglan and Mansour, 2018). Differences were reported using various study designs, including changes in anatomy and embalming students before and after lab courses and prevalence studies comparing exposed workers and referent groups. Generally, differences were observed at formaldehyde exposure levels averaging 0.2 mg/m^3^ and above. Micronuclei frequencies were greater by 1.5 to 6-fold in exposed workers with mean formaldehyde concentrations of 0.2 to 0.5 mg/m^3^ compared to referent groups (Viegas et al., 2010; Ladeira et al., 2011; Costa et al., 2019). Most of the studies of micronuclei frequency in buccal cells provided detailed discussions of design, methods, and results; potential confounders and other exposures that could pose a risk of genotoxicity were considered and excluded either in the design or data analysis. Associations with exposure duration also were observed by some researchers. Aglan (2018) analyzed micronuclei frequency in EBC from hair stylists who routinely conducted hair straightening treatments and compared them to a group of hair stylists who did not conduct these treatments. Formaldehyde concentrations can be high when hair straightening treatments are used, and 15-minute TWA concentrations greater than 1.9 mg/m^3^ were measured in this group. An increase in MN frequency was observed between the referent group and exposed groups stratified by exposure duration (below or above 5 years). However, there is more uncertainty in these results because reporting deficiencies prevented analysis of the potential for selection bias. While Costa (2019) reported a nonsignificant increase across tertiles of formaldehyde concentration above 0.2 ppm among anatomy/ pathology workers, the authors did not observe a trend in the frequency of nuclear buds across exposure duration from less than 8 years to over 14 years. Other studies of workers with mean exposure duration over 5 years also reported associations with exposure duration (Viegas et al., 2010; Ladeira et al., 2011).

Fewer studies are available that assessed micronuclei in nasal cells, but results were generally consistent. Significant differences in nasal micronuclei frequency were observed among anatomy students after an 8-week course (Ying et al., 1997), pathology workers compared to unexposed workers at the same institutions (Burgaz et al., 2001), and between formaldehyde production workers (Ye et al., 2005) or plywood production workers (Ballarin et al., 1992) compared to their referent groups. Formaldehyde concentrations among exposed groups averaged 0.1–>1.0 mg/m^3^. One study did not observe formaldehyde-related changes in nasal cells of embalming students (Suruda et al., 1993), but did report an increase in micronuclei with acentric fragments (centromere negative micronuclei) using fluorescence in situ hybridization (FISH) (Titenko-Holland et al., 1996). These results suggest that the predominant damage in these cells consisted of DNA and/or chromosomal breaks.

Most of a large set of studies that measured micronuclei in PBLs reported increased levels among exposed participants working in diverse exposure settings and in several countries (Ye et al., 2005; Wang et al., 2019; Viegas et al., 2010; Suruda et al., 1993; Souza and Devi, 2014; Orsiere et al., 2006; Ladeira et al., 2011; Jiang et al., 2010; He et al., 1998; Costa et al., 2008; Costa et al., 2011;Costa et al., 2013; Costa et al., 2019; Bouraoui et al., 2013; Aglan and Mansour, 2018). Several of these studies included a large sample size, and all provided detailed discussions of design, methods, and results, including how potential confounders and other exposures that could pose a risk of genotoxicity were considered and excluded, either in the design or data analysis. Costa et al. (2019) reported that the frequency of micronuclei in PBL and EBC were correlated in their study population. A clear concentration-related response in micronucleus frequency measured in PBLs was reported among plywood production workers in two studies that evaluated effects across multiple exposure categories (Ye et al., 2005; Jiang et al., 2010). Micronuclei frequency (and centromeric micronuclei) increased with cumulative exposure (Wang et al., 2019; Suruda et al., 1993) and the duration of exposure (Viegas et al., 2010; Souza and Devi, 2014; Lin et al., 2013; Ladeira et al., 2011; Jiang et al., 2010; Bouraoui et al., 2013; Aglan and Mansour, 2018). Observed effects were independent of confounding by age, gender, or smoking status.

A study of anatomy students did not observe changes in micronuclei in PBLs after an 8-week course, although increased levels were observed in buccal and nasal cells, suggesting that changes in lymphocytes may occur after a longer duration of formaldehyde exposure (Ying et al., 1997). Lin et al. (2013) did not observe an increase in micronucleus frequency across formaldehyde exposure categories among plywood workers in China. However, the referent group was exposed to mean concentrations of 0.13 mg/m^3^, a level associated with increased micronucleus frequency in another study of plywood workers (Jiang et al., 2010).

The sensitivity of the micronucleus assay can be enhanced by probing cells with pancentromeric DNA probes. A micronucleus that has a single centromere (C1 + MN) suggests chromosome migration impairment, and the presence of two or more centromeres (Cx + MN) indicates centromere amplification, with both conditions indicating aneuploidy (Iarmarcovai et al., 2006). Orsiere et al. (2006) and Bouraoui et al. (2013) evaluated micronuclei in lymphocytes using FISH and a pancentromeric probe and found increased levels of centromeric micronulei, including monocentromeric micronulei (C1 + MN) and multicentromeric micronuclei (Cx + MN) among exposed pathology and anatomy lab workers. The enhanced chromosome loss is consistent with the increase in aneuploidy in lymphocytes reported by Zhang et al. (2010).

#### DNA Damage

Most studies of DNA single-strand breaks, DNA crosslinks, apurinic or apyrimidinic sites, and sites with incomplete DNA repair using the Comet assay observed associations in PBLs with occupational formaldehyde exposure involving workers in plywood or furniture manufacturing, use of melamine resins, and in pathology laboratories (Zendehdel et al., 2017; Peteffi et al., 2015; Lin et al., 2013; Jiang et al., 2010; Gomaa et al., 2012; Costa et al., 2008; Costa et al., 2011; Costa et al., 2015) (see Table C-20). A 1.5- to 3-fold difference was observed comparing exposed groups to their referent groups at average concentrations as low as 0.09 mg/m^3^ (Zendehdel et al., 2017), 0.14 mg/m^3^ (Jiang et al., 2010) or 0.04–0.11 mg/m^3^ (Peteffi et al., 2015). A clear concentration-related response was observed in plywood plant workers (Lin et al., 2013; Jiang et al., 2010). In addition to the cross-sectional comparisons, an increased level of damage to DNA, indicated by increased tail moment levels in the Comet assay, was associated with formaldehyde exposure over an 8-hour work shift (Lin et al., 2013) and after an exposure for 4 hours/day for 5 days during a controlled human exposure study (Zeller et al., 2011). One study of workers in medium density fiberboard manufacture did not observe increases in Comet assay measures in the exposed group at a mean 8-hour TWA 0.25 ± 0.07 mg/m^3^ (Aydın et al., 2013). The range of exposure levels (0.12–0.41 mg/m^3^) was lower than most of the studies that evaluated DNA damage using the Comet assay, and almost half of the exposed workers in this study reported using personal protective equipment.

An increased level of DPXs was associated with formaldehyde exposure in a few studies, both across an 8-hour work shift (Lin et al., 2013), and in comparisons of formaldehyde-exposed workers and their referent groups (Shaham et al., 1997; Shaham et al., 2003). Lin et al. (2013) also compared DPX rates between formaldehyde-exposed plywood workers and a referent group but did not observe differences by exposure group. There was no trend across levels of exposure or duration of employment, possibly because the comparison group had significant exposure to formaldehyde (0.019–0.252 mg/m^3^) and workers had been employed only for a mean of 2.5 years. Shaham et al. (2003) found higher DPX levels in peripheral lymphocytes among a group of pathologists with a mean duration of exposure of 16 years compared to administrative workers from the same hospitals. While DPX levels in the exposed group were comparable to the exposed groups studied by Lin et al. (2013), DPX levels in the administrative workers were 60% lower than those measured in the referent group of woodworkers, perhaps reflecting their lower formaldehyde exposure. Analyses ruled out potential confounding by age, gender, smoking, education, and country of origin. Shaham et al. (2003) also observed higher levels of pantropic p53 protein (mutant plus wild-type protein) in serum in the exposed group compared to serum in the unexposed group, with a particularly strong association in males (pantropic p53 >150 pg/mL, adjusted OR = 2.0 (95% CI 0.9–4.4)). Increased serum pantropic p53 levels (p53 >150 pg/mL) was associated with mutant p53 content, and also with elevated DPX levels (OR = 2.5, 95% CI 1.2–5.4), suggesting a link between increases in DPX levels and overexpression of mutant p53 protein, an indication of loss of tumor suppressor gene capability.

Malondialdehyde-deoxyguanosine (M_1_dG) adducts in DNA extracted from whole blood were elevated in pathologists who spent time conducting tissue fixation (mean formaldehyde 0.212 ± 0.047 mg/m^3^) compared to workers and students in other science labs (Bono et al., 2010). The prevalence of M_1_dG DNA adducts was increased in the entire group of pathologists compared to the referent group among whom average formaldehyde concentrations were 0.028 mg/m^3^. Increased levels also were observed among a subgroup exposed to 0.07 mg/m^3^ formaldehyde and higher. This finding suggests the presence of formaldehyde-associated DNA damage concurrent with the induction of oxidative stress. An increase in oxidative stress, indicated by elevated plasma levels of malondialdehyde (MDA), was observed among employees at a cosmetic manufacturing company, who also had higher plasma levels of p53 compared to a group of employees in a hospital administrative department with no formaldehyde exposure (Attia et al., 2014). Although no air monitoring was conducted, the cosmetics workers had higher urinary formate levels compared to the referent group. Both plasma MDA and plasma p53 levels were related to urinary formate levels and also to each other. Regression analyses were adjusted for age and gender. Together, these two studies suggest that formaldehyde may increase systemic oxidative stress, which may be related to observed increases in peripherial white blood cell genotoxicity.

#### DNA Repair Protein Activity

O^6^-alkylguanine DNA alkyl-transferase activity in PBLs of students after 9 weeks or 3-months exposure to formaldehyde in embalming or anatomy labs was compared to enzyme activity prior to the beginning of the courses. Although an association with decreased activity was indicated in one study of embalming students (Hayes et al., 1997), this finding was not confirmed by a subsequent study of anatomy students (Schlink et al., 1999).

#### Susceptibility: Gene-Environment Interaction

A few studies of genotoxicity among formaldehyde-exposed groups also evaluated differences in subgroups defined by polymorphic variants in genes coding for proteins involved in the detoxification of xenobiotic toxic substances, including glutathione-S-tranferases (GSTM1, GSTT1, GSTP1), CYP2E1, and specifically, formaldehyde (alcohol dehydrogenase (ADH5) (see Table C-20). Polymorphisms in DNA repair proteins also were studied including the X-ray repair cross-complementing genes (XRCC1, XRCC2, XRCC3), RAD51, PARP1, and MUTYH. This included genes of the Fanconi anemia pathway (FANCA, BRIP1). The frequency of chromosomal aberrations in lymphocytes was higher in a formaldehyde-exposed group but did not vary by GSTT or GSTM polymorphism (Santovito et al., 2011). However, the GSTM1 null variant and the GSTP1 codon 105 Val allele were associated with an increased olive tail moment and MN frequency, respectively, among exposed individuals, but not in the referent group (Jiang et al., 2010). Costa et al. (2015) and Costa et al. (2019) also reported an increase in MN frequency in exfoliated buccal cells among exposed individuals with the Val variant in the GSTP1 rs1695 polymorphism, whereas chromosomal aberrations (CSAs) were more prevalent among the exposed group homozygous for the Ile allele. This research group also reported an increase in nuclear buds in buccal cells among exposed individuals with the A variant in the CYP2E1 rs6413432 polymorphism while exposed individuals homozygous for the wildtype T allele had a higher % tDNA measured in the comet assay. These associations were not observed in the referent group. In addition, the variant allele for the ADH5 Val309Ile polymorphism was associated with an increased frequency of micronuclei in lymphocytes among exposed individuals, but not in the referent group (Ladeira et al., 2013). The frequency of nuclear buds was associated with formaldehyde exposure and among carriers of the XRCC3 Met variant allele in both exposed and referent individuals, but effect modification was not apparent (Ladeira et al., 2013). Costa et al. (2019) did not observe associations with the XRCC gene polymorphisms and micronuclei frequency in EBC or PBL among formaldehyde exposed workers. However, micronuclei frequency was increased in PBL among exposed individuals with the Ala variant in the FANCA rs719823 variant. Therefore, genetic differences may alter susceptibility to the cytogenetic effects of formaldehyde, but more definitive research is needed.

Table C-20 Summary of genotoxicity of formaldehyde in human studies

Reference and study design | Exposure | Results
Chromosomal Damage and Induction of DNA repair
Prevalence Studies
Costa et al. (2015) Portugal; Prevalence study; Population: 84 anatomy pathology workers from 9 hospital laboratories, exposed to formaldehyde for at least 1 year, compared to 87 unexposed employees from administrative offices in same geographic area. Exclusions: cancer history, radiation therapy or chemotherapy, surgery with anesthesia or blood transfusion in last year. Exposed and referent similar for mean age 39 years, 77% females, 25% smokers.; Outcome: Peripheral blood samples, coded, analyses blinded to exposure status. Chromosomal aberrations (CAs) structural and numerical), duplicates cultured 51 hrs (cited (Roma-Torres et al., 2006)), 4% Giemsa stain; scored 100 metaphases per person, CTAs & CSAs according to Savage et al. (1976); gaps not included.; Exposed compared to unexposed using Mann-Whitney U-test for CA measures; negative binomial regression for untransformed total-CAs, CSAs, CTAs, gaps, aneuploidies, & aberrant cells; Poisson regression for untransformed multiaberrant cells. | Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.38 ppm (0.47 mg/m^3^); Range: 0.28–0.85 ppm (0.34–1.05 mg/m^3^); Exposure duration 12.0 ± 8.2 years | Comparison of exposed (N = 84) and referent (N = 87), frequencies of chromosomal aberrations (CA), structural and numerical
| | Aberration | | MR^a^ | | 95% CI
| | Total CA | | 1.91 | | 1.44–2.53
| | CSAs | | 2.07 | | 1.27–3.38
| | CTAs | | 1.86 | | 1.39–2.48
| | Gaps | | 1.65 | | 1.34–2.03
| | Aneuploidies | | 1.64 | | 1.36–1.98
| | Aberrant cells | | 1.66 | | 1.28–2.17
| | Multi-aberrant cells | | 3.96 | | 2.09–7.48
| | ^a^ MR – mean ratio; all models adjusted for age, gender and smoking habit, multi-aberrant cells MR also adjusted for fruit consumption (# pieces eaten per day)
| | No associations observed for models of formaldehyde exposure as continuous variable, exposure duration or professional activity on genotoxicity endpoints (data not provided by authors)
| | Mean SCE per cell in peripheral lymphocytes: ratio of exposed to referent
| | | | Ratio | | 95% CI
| | SCE/cell | | 1.27 | | 1.10- 1.46
| | Poisson regression adjusted for gender, smoking, and age.
Lan et al. (2015) China; Prevalence study; Population: 43 formaldehyde-melamine workers (95% employed for >1 year) compared to 51 workers from other regional factories no formaldehyde exposure frequency-matched by age and gender; participation rates exposed 92%, referent 95%; selected subset with scorable metaphases, high formaldehyde levels among exposed, comparable referents with scorable metaphases (29 exposed and 23 referent).; Outcome: Chromosome-wide aneuploidy in CFU-GM colony cells cultured for 14 d using OctoChrome FISH; scored minimum 150 cells/ subject; analysis blinded to exposure. Analyzed using negative binomial regression controlling for age and gender; incidence rate ratio (IRR). Also evaluated potential confounding from current smoking and alcohol use, recent infections, current medication use, and body mass index (Supplemental tables in the paper); Related reference: Zhang et al. (2010) | Personal monitors for 3 d over entire shift within a 3-wk period.; Formaldehyde concentration: 8 hr TWA; Exposed; Median: 1.38 ppm (1.7 mg/m^3^); 10^th^ & 90^th^ percentile: 0.78, 2.61 ppm (0.96, 3.2 mg/m^3^); Referent; 0.026 ppm (0.032 mg/m^3^); 10^th^ & 90^th^ percentile: 0.015, 0.026 ppm (0.019, 0.032 mg/m^3^); Formaldehyde LOD: 0.012 ppm; Personal sampling for organic compounds on 2 or more occasions. No chloroform, methylene chloride, tetrachloroethylene, trichloro-ethylene, benzene, or hydrocarbons were detected; urinary benzene at background levels and similar between groups | Among all 24 chromosomes analyzed, elevated IRR for monosomy found for chromosomes 1, 5, 7, 4, 19, 10, 16, 21, 2, 8, 18, 12, 20, 13, 6, and 14 (p < 0.05, Table 2 in Lan et al.); elevated IRR for trisomy found for chromosomes 5, 19, 21, 1, 20, and 16; elevated IRR for tetrasomy found for chromosomes 4, 15, 17, 14, 3, 18, 8, 12, 2, 10, and 6.
| | Selected Comparison of Chromosomal Aberration Rates*
| | Chromosome | | IRR | 95% CI | p-Value
| | Monosomy
| | 1 | | 2.31 | 1.61–3.31 | 6.02E-06
| | 5 | | 2.24 | 1.57–3.20 | 9.01E-06
| | 7 | | 2.17 | 1.53–3.08 | 1.57E-05
| | 4 | | 2.02 | 1.40–2.90 | 0.00015
| | 19 | | 1.74 | 1.29–2.34 | 0.00026
| | 10 | | 1.86 | 1.30–2.65 | 0.00064
| | 16 | | 1.54 | 1.12–2.12 | 0.0075
| | Trisomy
| | 5 | | 3.40 | 1.94–5.97 | 1.98E-05
| | 19 | | 2.07 | 1.24–3.46 | 0.0055
| | 21 | | 2.09 | 1.22–3.57 | 0.0071
| | Tetrasomy
| | 4 | | 1.64 | 1.21–2.21 | 0.0012
| | 15 | | 3.10 | 1.53–6.28 | 0.0017
| | 17 | | 2.40 | 1.33–4.32 | 0.0036
| | * Chromosomes with IRR with p-values < 0.001.
| | Increased frequency of structural chromosome aberrations in chromosome 5, IRR 4.15, 95% CI 1.20–14.35 (p = 0.024).
Santovito et al. (2014) Italy; Prevalence study; Population: 20 female nurses from 2 analogous departments in 2 hospitals (mean age 37 year); 20 unexposed from administrative departments of same hospital (mean age 39.6 year); all nonsmokers and did not consume alcohol; Outcome: Peripheral blood samples, coded. Cultures incubated for 48 hr for CA and 72 hr for SCE; CA slides stained with 5% Giemsa, scored 200 metaphases per subject, SCE 50 metaphases scored per subject; Mean frequencies compared, Wilcoxon test | All exposed used protective equipment; no formaldehyde measurements; nurses also exposed to antibiotics, cytostatic drugs, anesthetics and sterilants; Employment duration: Exposed 11.8 year, range 1–28 year; Referent 11.2 year, range 7–20 year | Frequency of Chromosomal Aberrations and SCEs among nurses and referent (mean ± SE)
| | | | # | Nurses | Referent
| | CA/ NSM | | 20 | 0.025 ± 0.003 | 0.02 ± 0.003
| | Cells with aberrations / NSM | | 20 | 0.025 ± 0.003 | 0.02 ± 0.003
| | SCEs/ NSM | | 20 | 6.55 ± 0.033* | 4.10 ± 0.37
| | NSM: number of scored metaphases; *p <0.001
| | No association CAs or SCEs with age or duration
Costa et al. (2013) Portugal; Prevalence study; Population: 35 pathology workers from 4 hospital laboratories, exposed to formaldehyde for at least 1 year (88.6% female, mean age 41.2 year, 20% smokers), compared to 35 unexposed employees from same work area (80% female, mean age 39.8 year, 20% smokers).; Outcome: SCE, coding and analysis blinded; stain fluorescence plus Giemsa, scored 50 M_2_ metaphases/ subject by 1 reader; Related references: Costa et al. (2008); Costa et al. (2011) | Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.44 mg/m^3^; Range: (0.28–0.85) mg/m^3^; Exposure duration 12.5 (1–30) years | Mean SCE per cell 1.3-fold higher in exposed workers compared to controls (p <0.05, Student’s t-test).; Univariate analyses presented in Figure 1 of Costa et al. (2013)
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.44 mg/m^3^; Range: (0.28–0.85) mg/m^3^; Exposure duration 12.5 (1–30) years | Mean SCE per cell in peripheral lymphocytes: ratio of exposed to referent
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.44 mg/m^3^; Range: (0.28–0.85) mg/m^3^; Exposure duration 12.5 (1–30) years | | | Ratio | | 95% CI
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.44 mg/m^3^; Range: (0.28–0.85) mg/m^3^; Exposure duration 12.5 (1–30) years | SCE/cell | | 1.245 | | 0.594–1.897
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.44 mg/m^3^; Range: (0.28–0.85) mg/m^3^; Exposure duration 12.5 (1–30) years | Multivariate analysis adjusted for gender, smoking, and age
Musak et al. (2013) Slovakia; Prevalence study; Population: 105 technicians and pathologists at hospital labs (79% female, mean age 41.7 years, 27.6% smokers) compared to 250 other medical staff (89% female, mean age 36.2 years, 19.2% smokers), all healthy.; Outcome: Differences in frequency of chromosomal aberration in peripheral blood lymphocytes, blinded analysis, 100 mitoses scored/ subject, 2 scorers | Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | Chromosomal aberrations in peripheral lymphocytes
| Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | Aberration | | OR | | 95% CI
| Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | CA | | 1.70 | | 1.6–2.72
| Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | CTA | | 1.37 | | 0.85–2.19
| Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | CSA | | 1.57 | | 0.98–2.53
| Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | Chromosomal exchange | | 2.6 | | 1.1–5.9
| Air monitoring once per year (no details provided).; Exposure conc.:; Mean: 0.32 mg/m^3^; Range: 0.14–0.66 mg/m^3^; Exposure duration:; Mean: 14.7 ± 10.4 years; Range: NR | Binary logistic regression controlling for age, gender, job type, and smoking
Gomaa et al. (2012) Egypt; Prevalence study; Population: 30 workers in pathology, histology and anatomy laboratories at a university (30% female, mean age 42.5 year) compared to 15 referents (46.7% female, mean age 39.3 year). Source of referent was not described.; Outcome: Chromosome aberrations in peripheral blood lymphocytes, cultured 72 hr, blinding not described; mean # per 100 metaphases; Difference between exposed and referent, Student’s t-test | No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Chromosomal aberrations in peripheral lymphocytes
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Structural | | Referent | | Exposed
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Chromatid gap & break | | 1.9 ± 0.36 | | 6.5 ± 0.65*
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Chromatid deletion | | 8.7 ± 0.55 | | 15.5 ± 0.47*
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Ring chromosome | | 5.5 ± 0.33 | | 16.4 ± 0.29*
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Dicentric chromosome | | 0.9 ± 0.41 | | 9.0 ± 0.54*
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Total | | 20.0 ± 0.27 | | 46.4 ± 0.35
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Numerical
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Aneuploidy | | 0.2 ± 0.12 | | 0.7 ± 0.10
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | Polyploidy | | 0.6 ± 0.14 | | 0.9 ± 0.09
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | * Student’s t-test, p <0.05; mean per 100 metaphases; ± SE
| No formaldehyde measurements; exposure defined by job type; Mean employment duration 14.3 year | No association with age or gender, ANOVA
Santovito et al. (2011) Italy; Prevalence study; Population: 20 pathology workers (70% female, mean age 45.7 year) compared to 16 workers from the same hospital (43.8% female, mean age 42.1 year). All subjects were non-smokers and had not consumed alcohol in 1 year.; Outcome: Frequency of chromosome aberrations per cell and mean % cells with aberrations; Venous blood sample collected at end of shift on same day as formaldehyde measurements, samples coded and processed within 4 hrs of collection, cells harvested 48 hr, 5% Giemsa stain, scored 100 metaphases/subject | Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; LOD 0.05 mg/mL; Exposure duration:; Mean: 13 years; Range: 2–27 years | Chromosomal aberrations in peripheral lymphocytes
| | | | Referent | | Exposed
| | Mean CA/cell | | 0.011 ± 0.004 | | 0.03 ± 0.004*
| | % of cells with aberrations | | 1.00 ± 0.342 | | 2.50 ± 0.286
| | *p <0.001, Mann-Whitney U test
| | Effects of exposure on chromosomal aberrations and cells with aberrations (coefficient (SE))
| | | | Exposure | | p- Value
| | # CA | | 0.960 (0.275) | | 0.001
| | # cell with aberrations | | 0.838 (0.287) | | 0.004
| | Generalized linear models with Poisson error distribution, adjusted for age
Jakab et al. (2010) Hungary; Prevalence study; Population: 37 female workers in 3 hospitals & 1 university pathology department (21 exposed to formaldehyde alone (mean age 43.3 year, 23.8% smokers), compared to 37 healthy female unexposed health-service staff (mean age 41.8 year, 16.2% smokers).; Outcome: Peripheral lymphocytes; CA, SCE, premature centromere division (PCD), mitoses with >3 chromosomes with PCD (centromere separation general (CSG)), CA stain 5% Giemsa, cells harvested 50 hr, scored 100 metaphases/ subject. SCE fluorescence plus Giemsa; scored 50 cells/ subject; analyses blinded | Exposure assessed via records on area air samples, measured within 1–3 years of data collection.; Exposure Concentration: 8-hr TWA: 0.9 mg/m^3^; Range: 0.23–1.21 mg/m^3^; Exposure duration:; Mean: 17.7 years; Range: 4–34 years | Cytogenetic analysis in cultured peripheral lymphocytes (mean ± SD)
| | | | Unexposed | | Exposed
| | Total CA | | 1.62 ± 0.26 | | 3.05 ± 0.62^*^
| | Chromatid-type aberrations | | 1.00 ± 0.20 | | 2.35 ± 0.46*
| | Chromosome-type aberrations | | 0.62 ± 0.18 | | 0.70 ± 0.26
| | Aneuploidy | | 8.89 ± 0.66 | | 5.4 ± 0.61*
| | SCE (%/cell) | | 6.16 ± 0.16 | | 6.36 ± 0.26
| | High frequency SCE | | 3.76 ± 1.14 | | 7.05 ± 2.19
| | PCD (%) | | 7.6 ± 0.84 | | 13.65 ± 1.59*
| | PCD (CSG) | | 5.57 ± 0.66 | | 8.8 ± 1.07*
| | *p <0.05, Student’s t-test, compared to controls
| | SCE % and mean HF/SCE higher in referent and exposed smokers; mean SCE % associated with older age
Zhang et al. (2010) China; Prevalence study; Population: 43 formaldehyde-melamine workers (95% employed for >1 year) compared to 51 workers from other regional factories frequency-matched by age and gender; participation rates exposed 92%, referent 95%; Analyzed subset of exposed (n = 10, 9 male, 1 female, mean age 31 year) and referent (n = 12, 11 male, 1 female, mean age 32 year); Outcome: Chromosome aberration in peripheral blood cells, blinded to exposure. Chromosome aneuploidy in cultured CFU-GM colony cells using FISH; monosomy 7 and Trisomy 8; scored minimum 150 cells/ subject.; Related references: Mundt et al. (2017); Lan et al. (2015); Gentry et al. (2013) | Personal monitors for 3 d within a 3-wk period. Formaldehyde concentration: 8 h TWA; Exposed; Median: 1.57 mg/m^3^; 10^th^ & 90^th^ percentile: 0.74, 3.08 mg/m^3^; Referent; 0.039 mg/m^3^; 10^th^ & 90^th^ percentile: 0.022, 0.039 | Leukemia-specific chromosome changes:; Significant increase chromosome aneuploidy in cultured CFU-GM colony cells among subset of high exposed (n = 10) compared to matched controls (n = 12); Data provided in Figure 4 of Zhang et al. (2010).; Analyzed using negative binomial regression (exposed compared to unexposed) controlling for age, gender, and smoking; Mundt et al. presented individual data in graphs for chromosome 7 and chromosome 8 (n = 10 exposed and n = 12 controls), noting smoking status and whether 150 or more cells were evaluated. No patterns apparent.
Costa et al. (2008) Portugal; Prevalence study; Population: 30 pathology lab workers (4 hospitals), (70% female, mean age 38 year, 27% smokers) compared to 30 administrative employees matched by age, gender, lifestyle, smoking habits and work area (63.3% female, mean age 37 years, 23% smokers).; Outcome: Peripheral lymphocytes; blood samples collected 10–11 am; processed immediately; stain fluorescence plus 5% Giemsa, SCE/ cell 50 s division metaphases scored by one observer, Scored blind to exposure status. Effect of smoking and gender also analyzed | Exposure assessed via air sampling at breathing zone and deriving an 8-hr TWA for each subject; Concentration:; Mean: 0.54 mg/m^3^; Range: (0.05–1.94) mg/m^3^; Duration: 11 years; Range: (0.5–27) years | Mean SCE per cell in peripheral lymphocytes
| | | | Controls | | Exposed
| | SCE/ cell | | 4.49 ± 0.16 | | 6.13 ± 0.29*
| | *p <0.05, Student’s t-test
| | No association of SCE with gender or age. Smoking increased SCE among referent group (smoking prevalence 23% in referent, 27% in exposed.; No association of SCE with duration of exposure
Pala et al. (2008) Italy; Prevalence study; Population: 36 lab workers (66.7% female, mean age 40.1 year, 16.7% smokers); Outcome: CA and SCE, in peripheral lymphocytes (blood sampled at end of 8-hr) Blinded analyses, CA: cells harvested at 48 hr, 100 metaphases/ subject, SCE: harvest at 72 hr, 30 2^nd^ division cells/ subject. | Personal air monitoring (8-hr sample); High exposure group: ≥ 0.026 mg/m^3^, 75^th^ percentile (range 0.005–0.269 mg/m^3^) and low-exposure group: <0.026 mg/m^3^; Concentration:; Low (n = 27): 0.015 (0.005–0.0254) mg/m^3^; High (n = 9): 0.056 (0.026–0.269) mg/m^3^ | Frequency chromosomal aberrations in peripheral lymphocytes
| | | | CA | | SCE
| | < 0.026 mg/m^3^ | | 2.95 ± 1.79 (n=19) | | 6.57 ± 1.38 (n=17)
| | ≥ 0.026 mg/m^3^ | | 2.22 ± 1.27 (n=5) | | 5.06 ± 0.76 (n=2)
| | Means ratio (95% CI) | | 0.83 (0.42–1.64) | | 0.81 (0.56–1.18)
| | Multivariate regression models adjusting for gender, age and smoking; Poisson model for CA, SCE log-normal random effects model; Authors did not use a referent group
Ye et al. (2005) China; Population: 18 workers at a formaldehyde plant at least 1 year (38.9% female, mean age 29 year, and 16 workers exposed to indoor air formaldehyde via building materials (75% female, mean age 22 year) compared to 23 students with no known source of formaldehyde exposure (dormitories) (48% female, mean age 19 year); all nonsmokers; Outcome: SCE in peripheral lymphocytes, time of sample not stated; stain Giemsa solution, analysis blinded, 30 M_2_ lymphocytes analyzed/ subject. | Area samples;; Exposure duration:; Workers 8.5 (1–15) years; Waiters 12 wks; TWA Concentration; Controls; 0.011 ± 0.0025 mg/m^3^; Max. 0.015 mg/m^3^; Wait staff; 0.107 ± 0.067 mg/m^3^; Max. 0.30 mg/m^3^; Workers; 0.985 ± 0.286 mg/m^3^; Max. 1.694 mg/m^3^ | SCE frequency by exposure group
| | | | Referent | Wait Staff | Formaldehyde workers
| | Mean SCE | | 6.38 ± 0.41 | 6.25 | 8.24 ± 0.89*
| | *p <0.05, ANOVA. Values estimated from graph in Figure 2 of Ye et al.
(Shaham et al., 2002); Israel; Prevalence study; Population: 90 workers from 14 hospital pathology departments (65 females, 25 males; mean age 44.2 year, 34% smokers) compared to 52 administrative workers from the same hospitals (8 females, 44 males; mean age 41.7 year, 46.9% active smokers, 53.1% nonsmokers); Outcome: SCE in peripheral lymphocytes; Mean # SCEs per chromosome and proportion of high frequency cells compared between exposed and referent. High frequency cells defined as > 8 SCEs; blinding not described, stain fluorescence plus 5% Giemsa, scored 30–32 cells/ subject. Related references: Shaham et al. (1997) | Personal and area samples, sampling at different points in work day, sampling duration averaged 15 min; Exposure concentration:; Low level exposure:; Mean: 0.49 mg/m^3^; Range: 0.05–0.86 mg/m^3^; High level exposure:; Mean: 2.76 mg/m^3^; Range: 0.89–6.89 mg/m^3^; Exposure duration:; Mean: 15.4 years; Range: 1–39 years | SCE frequency in peripheral lymphocytes by exposure group and smoking status (mean ± SE)
| | | | Mean number SCEs per chromosome | | Mean proportion of high frequency cells
| | Unexposed | | 0.19 ± 0.004 | | 0.44 ± 0.02
| | Exposed | | 0.27 ± 0.003* | | 0.88 ± 0.01*
| | No smoking
| | Low | | 0.28 ± 0.004 | | 0.88 ± 0.015
| | High | | 0.26 ± 0.021 | | 0.86 ± 0.016
| | Smoking
| | Low | | 0.27 ± 0.007 | | 0.89 ± 0.018
| | High | | 0.28 ± 0.006 | | 0.92 ± 0.021
| | *p <0.01, ANOVA adjusting for age, gender, smoking status, education years and origin (ethnicity)
| | No association with exposure duration (≤15 years and >15 years) with adjustment for age, gender, smoking status, education years and origin (ethnicity)
Lazutka et al. (1999) Lithuania; Prevalence study; Population: Carpet and plastic manufacturing; Carpet plant, exposed, 38 male, 41 female (age 22–65 year, 49% smokers); unexposed, 64 male, 26 female, 30% smokers; Plastic plant, exposed 34 male, 63 female (age 28–64 year, 37% smokers); unexposed 64 males, 26 females; Outcome: CA in peripheral blood lymphocytes; fluorescence plus Giemsa stain, cells harvested 72 hr, scored 100 metaphases/ subject on coded slides. | Industrial hygiene area measurements reported by plants;; carpet plant, formaldehyde 0.3–1.2 mg/m^3^, styrene 0.13–1.4 mg/m^3^, phenol 0.3 mg/m^3^;; plasticware plant, formaldehyde 0.5–0.9 mg/m^3^, styrene 4.4–6.2 mg/m^3^, phenol 0.5–0.75 mg/m^3^; Duration exposure, carpet plant: 2 mo-21 year; plastic plant: 2 mo–25 year | Frequency of chromosomal aberrations in peripheral blood lymphocytes by exposure (CA/ 100 cells ± SEM)
| | | | # | | CA Frequency
| | Carpet Workers
| | Exposed | | 79 | | 3.79 ± 0.32*
| | Referent | | 90 | | 1.68 ± 0.13
| | Plasticware workers
| | Exposed | | 97 | | 4.17 ± 0.29*
| | Referent | | 90 | | 1.68 ± 0.13
| | *p < 0.0001; ANOVA adjusted for age
| | Predominant types of damage were chromatid and chromosome breaks; Duration of exposure not associated with CA frequency; Age and smoking (data not shown) were not associated with CA frequency
Shaham et al. (1997) Israel; Prevalence study; Population: 13 pathology workers (mean age 42 year, 23% smokers) compared to 20 referent workers matched by age (mean age 39 year, 30% smokers).; Outcome: SCE in peripheral lymphocytes, Mean # per chromosome, stain fluorescence plus 5% Giemsa, blinding not described, mean of 30 cells/ individual,; Related references: Shaham et al. (1996) | Field and personal air sampling, sample duration 15 min, multiple times during work-day (# not reported).; Concentration:; Mean: not reported; Range: 1.7–1.97 mg/m^3^; Personal samples:; Range: 3.4–3.8 mg/m^3^; Exposure duration mean 13 years (range 2–25 years) | SCE (mean # per chromosome) in peripheral lymphocytes
| | | | Unexposed | | Exposed
| | SCE | | 0.186 ± 0.035 | | 0.22 ± 0.039*
| | *p = 0.05, ANOVA adjusted for smoking status
| | years of exposure linearly correlated with mean number of SCE per chromosome, adjusting for smoking
Kitaeva et al. (1996) Russia (translated); Prevalence study; Population: 15 formaldehyde production workers (5 females, 10 males, mean age 38 year), anatomy instructors (6 female, 2 male), mean age 41 year) compared to 6 unexposed (mean age 28.5 year); Outcome: Blood collection in 1988. CA: cells harvested at 72 hr; blinding not described. Unclear if statistical analyses were performed. | No quantitative exposure assessment; Exposure duration:; Formaldehyde production 9.7 years; Anatomy instructors 17 years | CA (% aberrant metaphases) in peripheral lymphocytes
| No quantitative exposure assessment; Exposure duration:; Formaldehyde production 9.7 years; Anatomy instructors 17 years | | | Referent (n=6) | | Exposed Workers (n=8)
| No quantitative exposure assessment; Exposure duration:; Formaldehyde production 9.7 years; Anatomy instructors 17 years | % of metaphases at 72 hrs lymphocyte culture | | 1.8 ± 0.6 (547 metaphases examined) | | 5.4 ± 1.9 (148 metaphases examined)
| No quantitative exposure assessment; Exposure duration:; Formaldehyde production 9.7 years; Anatomy instructors 17 years | No metaphases observed at 72 hrs in lymphocyte cultures from anatomy instructors; Authors reported that % CA was not dependent on age, gender and length of employment
Vasudeva and Anand (1996) India; Prevalence study; Population: 30 female medical students exposed 15 mos, compared to 30 age-matched nonmedical students. All 17–19 years old; Outcome: chromosomal aberrations in peripheral blood samples, mean frequency aberrant metaphases, cells harvested at 72 hr, 100 cells/ subject; blinding not reported. | Exposure not quantified; Exposure conc.: < 1.23 mg/m^3^; Exposure duration: 15 mos | No significant difference in chromosomal aberrations between groups (p >0.5).; Mean frequency of aberrant metaphases; Exposed: 1.2%; Unexposed: 0.9%; No additional quantitative information available
Vargová et al. (1992) Czechoslovakia; Prevalence study; Population: 20 wood workers with at least 5 years of exposure (10 females, 10 males, mean age 42.3 year), compared to 19 workers from the same plant with no known occupational contact with chemicals.; Outcome: CA frequency, peripheral lymphocytes, Giemsa staining, cells harvested 48 hr, 100 cells/ subject. Blinding not described. | Task-based air sampling in breathing zone over 8 hours; Exposure conc.:; Range: 0.55–10.36 mg/m^3^; Exposure duration: 5–>16 years | Frequency of chromosomal aberrations in peripheral lymphocytes by exposure group
| Task-based air sampling in breathing zone over 8 hours; Exposure conc.:; Range: 0.55–10.36 mg/m^3^; Exposure duration: 5–>16 years | | | Exposed | | Unexposed^a^
| Task-based air sampling in breathing zone over 8 hours; Exposure conc.:; Range: 0.55–10.36 mg/m^3^; Exposure duration: 5–>16 years | % aberrant cells | | 3.08 | | 3.60
| Task-based air sampling in breathing zone over 8 hours; Exposure conc.:; Range: 0.55–10.36 mg/m^3^; Exposure duration: 5–>16 years | # breaks per cell^a^ | | 0.045 | | 0.030
| Task-based air sampling in breathing zone over 8 hours; Exposure conc.:; Range: 0.55–10.36 mg/m^3^; Exposure duration: 5–>16 years | ^a^ According to authors, both groups reported % aberrant cell levels above normal range (1.2–2%)
Bauchinger and Schmid (1985) Germany; Prevalence study; Population: 20 male paper makers exposed for at least 2 years (mean age 40.8 year, 30% smokers) compared to 20 unexposed male workers from the same factory; Outcome: Peripheral lymphocytes, CA/ cell (scored 500 cells/ subject), cells harvested 48 hr, Giemsa staining; SCE/ cell (scored 50/ subject) analyzed using coded slides, SCE stratified by smoking status. | Exposure assessment based on air monitoring and job-function.; Exposure concentration.: ≈1.47 mg/m^3^, plus 3.7 mg/m^3^ for 45 min (supervisors) or 90 min (operators) per 8 hrs; Exposure duration; Mean: 14.5 years; Range: 2–30 years | Frequency of CA and SCE/cell (mean ± SE) in peripheral lymphocytes
| | | | Referent | | Exposed
| | % cell with CA | | 0.86 ± 0.10 | | 0.87 ± 0.08
| | SCE/ cell | | 9.53 ± .0.35 | | 8.87 ± 0.24
| | Aberrations/ cell
| | Chromatid | | 0.0038 ± 0.0005 | | 0.0042 ± 0.0005
| | Acentric fragments | | 0.0046 ± 0.0006 | | 0.0034 ± 0.0005
| | Dicentrics | | 0.0005 ± 0.0002 | | 0.0013 ± 0.0003*
| | Centric rings | | 0.0001 ± 0.0001 | | 0.0003 ± 0.0001*
| | *p <0.05, Mann-Whitney rank U test
| | Frequency of SCE was not associated with exposure when stratified by smoking
Thomson et al. (1984) Great Britain; Prevalence study; Population: 6 pathology workers (2 female, 4 male, mean age 33.5 year) compared to 5 referents (3 female, 2 male, mean age 27.8 year) (study details on referent not provided); Outcome: CA frequency, stain fluorescence plus Giemsa technique (Perry and Wolff, 1974), cells harvested 48 hr, slides coded and scored 100 1^st^ division metaphases/ subject; SCE frequency, cells harvested 72 hr, 50 cells/ subject | Personal air monitoring over 1–3 mos before blood samples; Exposure conc.: TWA; Mean: 2.26 mg/m^3^; Range: 1.14–6.93 mg/m^3^; Exposure duration: 4–11 years, 2–4 hr/d, 2–3 d/wk | No significant difference in incidence of chromosome aberrations or SCE frequency found between groups.; SCE frequency (mean per cell); Exposed (N = 6) 6.78 ± 0.31; Referent (N = 5) 6.44 ± 0.38; (individual data reported, analytic methods were not described)
Fleig et al. (1982) Germany; Prevalence study; Population: 15 formaldehyde-manufacturing workers (mean age 50 year) compared to 15 age-and gender matched unexposed workers from same plant.; Outcome: Chromosome aberrations in peripheral blood lymphocytes cells harvested 70–72 hrs, 10% Giemsa stain; slides coded; scored 100 metaphases/ subject. | Personal air sampling.; 1946–1971: <6.15 mg/m^3^ (MAK); 1971–1982: <1.23 mg/m^3^ (MAK); Duration:; Mean: 28 years; Range: 23–35 years | Chromosomal aberrations in peripheral blood lymphocytes
| Personal air sampling.; 1946–1971: <6.15 mg/m^3^ (MAK); 1971–1982: <1.23 mg/m^3^ (MAK); Duration:; Mean: 28 years; Range: 23–35 years | | | Unexposed | | Exposed
| Personal air sampling.; 1946–1971: <6.15 mg/m^3^ (MAK); 1971–1982: <1.23 mg/m^3^ (MAK); Duration:; Mean: 28 years; Range: 23–35 years | Mean % aberrant cells including gaps | | 3.33 | | 3.07
| Personal air sampling.; 1946–1971: <6.15 mg/m^3^ (MAK); 1971–1982: <1.23 mg/m^3^ (MAK); Duration:; Mean: 28 years; Range: 23–35 years | Mean % aberrant cells excluding gaps | | 1.07 | | 1.67
| Personal air sampling.; 1946–1971: <6.15 mg/m^3^ (MAK); 1971–1982: <1.23 mg/m^3^ (MAK); Duration:; Mean: 28 years; Range: 23–35 years | P >0.05, Fisher’s exact text
| Personal air sampling.; 1946–1971: <6.15 mg/m^3^ (MAK); 1971–1982: <1.23 mg/m^3^ (MAK); Duration:; Mean: 28 years; Range: 23–35 years | Smoking habit not associated with CA (data not reported)
Suskov and Sazonova (1982) Russia; Prevalence study; Population: 31 phenol-formaldehyde workers (mean age 39.1 year) compared to 74 referents matched by gender, smoking, alcohol consumption, and medication; Outcome: Chromosomal aberrations via mean frequency of aberrant metaphases, Buckton and Evans (1973) method; cells harvested at 50 hr | Workers exposed to both phenol and FA. Area samples; Exposure conc.:; Formaldehyde Mean: 0.5 mg/m^3^; Phenol mean: 0.3 mg/m^3^; Exposure duration:; 4 mos to 30 years | Frequency of chromosomal aberrations by exposure group
| Workers exposed to both phenol and FA. Area samples; Exposure conc.:; Formaldehyde Mean: 0.5 mg/m^3^; Phenol mean: 0.3 mg/m^3^; Exposure duration:; 4 mos to 30 years | Mean % aberrant cells | | Referent | | Exposed
| Workers exposed to both phenol and FA. Area samples; Exposure conc.:; Formaldehyde Mean: 0.5 mg/m^3^; Phenol mean: 0.3 mg/m^3^; Exposure duration:; 4 mos to 30 years | Aberrant metaphases | | 2.4 ± 0.22 | | 5.0 ± 0.40*
| Workers exposed to both phenol and FA. Area samples; Exposure conc.:; Formaldehyde Mean: 0.5 mg/m^3^; Phenol mean: 0.3 mg/m^3^; Exposure duration:; 4 mos to 30 years | Aberrant chromosomes per cell | | 0.024 ± 0.002 | | 0.058 ± 0.006*
| Workers exposed to both phenol and FA. Area samples; Exposure conc.:; Formaldehyde Mean: 0.5 mg/m^3^; Phenol mean: 0.3 mg/m^3^; Exposure duration:; 4 mos to 30 years | Chromosomal breaks per aberrant chromosome | | 1.26 ± 0.076 | | 1.27 ± 0.044
| Workers exposed to both phenol and FA. Area samples; Exposure conc.:; Formaldehyde Mean: 0.5 mg/m^3^; Phenol mean: 0.3 mg/m^3^; Exposure duration:; 4 mos to 30 years | *p <0.001, chi-square
Short-term Studies
Ying et al. (1999) China; Population: 23 nonsmoking anatomy students (11 males, 12 females, age not reported) exposed during 8-week course, 3-hr session, 3 times/ wk.; Outcome: SCE in peripheral blood lymphocytes, assessed before the start of the course and at the end of 8-week period. Blinded analysis of slides, one observer with repeat by second; 30 M_2_ lymphocytes per subject analyzed; Lymphocyte transformation rate (LTR) | Air sampling, estimated TWA and peak levels during class and in the dorms.; Anatomy labs:; Mean 3-hr TWA: 0.51 ± 0.299 mg/m^3^, range: 0.07–1.28 mg/m^3^; Dormitories:; Mean TWA: 0.012 ± 0.003 mg/m^3^, range: 0.011–0.016 mg/m^3^; Duration: 8 wks | Frequency SCE and lymphocyte transformation rate (LTR) (%) (Mean+SEM), Change over 8 wks
| | | | Before exposure | | After exposure
| | SCE | | 6.383 ± 0.405 | | 6.613 ± 0.786
| | LTR | | 59.07 ± 6.35 | | 56.92 ± 8.64
| | *p <0.05, paired t-test
| | Levels in males and females were similar
He et al. (1998) China; Prevalence study; Population: 13 anatomy students exposed during a 12-week course compared to 10 students. Age and gender similar between groups, all nonsmokers (data not shown).; Outcome: CA and SCE in peripheral lymphocytes, CA: modified fluorescence plus Giemsa stain, cells harvested 48 hr, scored 100 metaphases/ subject. SCE: cells harvested 72 hr, 50 metaphases/ subject. Blinding not described | Breathing zone air samples in location of exposed students.; Concentration in breathing zone: Mean 2.92 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | Frequency of SCE and chromosomal aberrations in peripheral lymphocytes
| Breathing zone air samples in location of exposed students.; Concentration in breathing zone: Mean 2.92 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | | | Referent | | Exposed
| Breathing zone air samples in location of exposed students.; Concentration in breathing zone: Mean 2.92 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | Mean SCE per cell | | 5.26 ± 0.51 | | 5.91 ± 0.71*
| Breathing zone air samples in location of exposed students.; Concentration in breathing zone: Mean 2.92 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | Lymphocyte CA | | 3.40 ± 1.57 | | 5.92 ± 2.40*
| Breathing zone air samples in location of exposed students.; Concentration in breathing zone: Mean 2.92 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | *p <0.05, analytic test not described
Suruda et al. (1993) USA; Panel study; Population: 29 students (with adequate samples) (24.1% female, mean age 23.6 year, 17.2% smokers) exposed to formaldehyde for 9 wks during embalming course, with baseline samples taken. Mean duration of embalming 125 min. Possible exposure prior to course.; Outcome: SCE in peripheral lymphocytes, stain fluorescein plus Giemsa, 50 s division metaphases scored/ subject; blood samples collected in morning before 1^st^ class and after 9 wks; analysis of slides blinded to exposure status | Personal sampling for 121 of 144 embalmings;; Exposure concentration:; Mean: 1.72 mg/m^3^; Range: (0.18–5.29) mg/m^3^; Duration:; 9 wks (0.173 years) | Frequency of SCE before and after a 9-wk embalming course
| Personal sampling for 121 of 144 embalmings;; Exposure concentration:; Mean: 1.72 mg/m^3^; Range: (0.18–5.29) mg/m^3^; Duration:; 9 wks (0.173 years) | | | Before exposure | | After exposure
| Personal sampling for 121 of 144 embalmings;; Exposure concentration:; Mean: 1.72 mg/m^3^; Range: (0.18–5.29) mg/m^3^; Duration:; 9 wks (0.173 years) | SCE | | 7.72 ± 1.26 | | 7.14 ± 0.89*
| Personal sampling for 121 of 144 embalmings;; Exposure concentration:; Mean: 1.72 mg/m^3^; Range: (0.18–5.29) mg/m^3^; Duration:; 9 wks (0.173 years) | *p <0.01, difference in mean before and after exposure, matched Student’s t-test
Yager et al. (1986) USA; Panel study; Population: 8 anatomy students (1 male, 7 females, mean age 26 year, all nonsmokers) exposed to formaldehyde during a 10 wk course (2 sessions/ wk). No occupational or lab formaldehyde exposure during previous year.; Outcome: Mean SCEs per cell in peripheral lymphocytes; before and after 10 wks, samples coded and randomized together for analysis | Ambient air and breathing zone monitoring.; Breathing zone concentration:; Mean:1.5 mg/m^3^; Range: 0.9–2.4 mg/m^3^; Exposure duration:; 10 wks | Mean SCE per cell before and after 10-wk course (mean ± SEM)
| Ambient air and breathing zone monitoring.; Breathing zone concentration:; Mean:1.5 mg/m^3^; Range: 0.9–2.4 mg/m^3^; Exposure duration:; 10 wks | | | Before | | After
| Ambient air and breathing zone monitoring.; Breathing zone concentration:; Mean:1.5 mg/m^3^; Range: 0.9–2.4 mg/m^3^; Exposure duration:; 10 wks | Mean SCE per cell | | 6.39 ± 0.11 | | 7.20 ± 0.33*
| Ambient air and breathing zone monitoring.; Breathing zone concentration:; Mean:1.5 mg/m^3^; Range: 0.9–2.4 mg/m^3^; Exposure duration:; 10 wks | *p = 0.02, paired t-test
Zeller et al. (2011) Germany; Controlled human exposure study; Subjects: 41 healthy volunteers exposed 4 hr/d for 5 d, all male, nonsmokers; Outcome: SCE in peripheral lymphocytes: method according to Schmid and Speit (2007), scored 30 cells/ sample. Proliferation index (PI) calculated from 1^st^, 2^nd^, and 3^rd^ mitoses in 100 metaphases. Analyzed using Wilcoxon Sign Rank test | 12 groups of 2 to 4 persons in a chamber, exposures randomly assigned.; Formaldehyde concentrations: 0 (i.e., background level of 0.01 ppm); 0.3 ppm (0.37 mg/m^3^)^a^ with 4 peaks of 0.6 ppm (0.74 mg/m^3^); 0.4 ppm (0.49 mg/m^3^) with four peaks of 0.8 ppm (0.98 mg/m^3^); 0.5 ppm (0.67 mg/m^3^); and 0.7 ppm (0.86 mg/m^3^); Peaks were 15 min each, Four 15-min exercise sessions during exposure. | Frequency of SCE/ metaphase and PI in lymphocytes before and after 4-hour exposure (N = 40)
| | | | SCE/metaphase | | PI
| | Lymphocytes
| | Before | | 6.1 ± 0.898^a^ | | 2.46 ± 0.114
| | After | | 6.1 ± 0.938 | | 2.47 ± 0.145
| | ^a^p = 0.689
Chromosomal Breaks or Aneuploidy
Prevalence Studies
Aglan and Mansour (2018) Egypt; Prevalence study, June 2015 - September 2016; Population: 60 hair stylists who routinely conducted hair straightening compared to 60 stylists who did not conduct this treatment. Excluded subjects with chronic disease and /or regular medications, family history of cancer, recurrent abortions, smoking or pregnancy. Ages 20–36 years.; Outcome: Blood collected at end of 8-hr shift.; CB Micronucleus test in lymphocytes. Replicate cultures for each sample, incubated 72 hrs. 2,000 binucleasted cells from coded slides (1,000 from each replicate culture), scored using criteria by Fenech et al. (2003). MN frequency % altered cells.; MN in exfoliated buccal cells. Cheeks scraped with wooden spatula, fixed in 3:1 methanol/ acetic acid and dropped onto slides, stained with Feulgen/ Fast Green, examined at 400× according to Tolbert et al. (1991). Analyzed independently by 2 people, 1,500 cells scored per person using criteria by Sarto et al. (1987). % altered cells. | Passive air sampling (Umex-100) at fixed position in breathing zone, 15-min samples during hair straightening process; 15-min TWA; Group 1 (work duration < 5 years): 1.68 ± 0.27 ppm; Group 2 (work duration > 5 years): 1.83 ± 0.16 ppm | MN frequency (%) in PBL and buccal cells by duration of employment (< 5 and > 5 years)
| | | | PBL | | EBC
| | | | Mean ± SD | | Mean ± SD
| | Referent (n=60) | | 0.22 ± 0.42^*^ | | 0.17 ± 0.38^**^
| | < 5 yrs (n=31) | | 0.61 ± 0.50 | | 0.32 ± 0.48
| | > 5 yrs (n=29) | | 1.66 ± 0.48 | | 0.94 ± 0.58
| | ^*^ p < 0.01, ^**^ p < 0.001, Kruskal Wallis test
| | Between group differences statistically significant in PBL and for EBC except between referent and < 5 year exposure group (least significant difference test)
Costa et al. (2019) Portugal; Prevalence study (extension of Costa et al. (2015)).; Population: 85 anatomy pathology workers from 9 hospital laboratories, exposed to formaldehyde for at least 1 year, compared to 87 unexposed employees from administrative offices in same geographic area. Exclusions: cancer history, radiation therapy or chemotherapy, surgery with anesthesia or blood transfusion in last year. Exposed and referent similar for mean age 39 years, 77% females, 25% smokers.; Outcome: Peripheral blood samples, coded, analyses blinded to exposure status. Exfoliated cells were collected for each cheek separately. Cytokinesis-blocked MN test, Costa et al. (2008); culture incubation 72 hr; stain 4% Giemsa; scored 1,000 binucleated cells/subject, criteria defined by Fenech (2007).; Buccal MN cytome assay. 2,000 differentiated cells scored for frequency of MN, nuclear buds and nucleoplasmic bridges according to Tolbert et al. (1991) and Thomas et al. (2009).; T-Cell Receptor mutation assay in mononuclear leukocytes, flow cytometry, minimum of 2.5 × 105 lymphocyte-gated events were acquired, # events in mutation cell window (CD3-CD4+ cells) divided by total number of events for CD4+ cells | Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.38 ppm (0.47 mg/m^3^); Range: 0.28–1.39 ppm (0.34–1.72 mg/m^3^); Exposure duration 12.0 ± 8.2 years | MN frequency (%) in peripheral lymphocytes, exposed relative to referent group, Mean Ratio (MR)
| | | | Ratio | | 95% CI
| | Exposure | | 1.55** | | 1.2–1.99
| | Poisson regression models adjusted for age, gender, smoking habits; **p <0.01
| | MN frequency in exfoliated buccal cells, Mean Ratio (MR)
| | | | Exposed: Unexposed | MR | 95% CI
| | MNB | | 63:69 | 4.08*** | 2.12 – 7.87
| | BNbud | | 63:69 | 2.88*** | 1.76 – 4.71
| | Poisson regression models adjusted for age, gender, smoking habits; ***p < 0.001
| | Correlation between MNL and MNB: r = 0.359, p < 0.001
| | MN frequency in PBL and exfoliated buccal cells by level and duration in exposed, Mean Ratio (MR)
| | | MNL | | 95% CI | BNbud | | 95% CI
| | | N | MR | 95% CI | N | MR | 95% CI
| | Level (ppm)
| | 0.08-0.22 | 27 | 1.0 | | 20 | 1.0
| | 0.23-0.34 | 29 | 1.5** | 1.12-2.00 | 16 | 1.42 | 0.64-3.14
| | 0.35-1.39 | 28 | 1.37* | 1.04-1.81 | 17 | 1.96 | 0.91-4.24
| | Duration years
| | < 8 | 28 | 1.0 | | 25 | 1.0
| | 8-14 | 28 | 0.78 | 0.51-1.23 | 18 | 0.74 | 0.30-1.78
| | > 14 | 28 | 0.68 | 0.40-1.15 | 20 | 1.00 | 0.37-2.74
| | Poisson regression models adjusted for age, gender, smoking habits; *p < 0.05; **p < 0.01.
Wang et al. (2019) Shanghai, China; Population: 100 male chemical production workers exposed to formaldehyde > 1 year through 4 work processes (i.e., production examination, glue spraying, coating and workplace inspection). Unexposed group (n = 100 males) from the logistics workshop in same factory.; Exposed and referent were comparable for mean age, smoking and alcohol consumption.; Outcome: CBMN according to Fenech (1993, 2000). Blinded analysis. Venous peripheral blood cultured for 44 hr, Cytochalasin-B added to cultures, cells harvested 28 hrs later, air dried slides stained with Giemsa, MN dectected at 400× with confirmation at 1,000×. 1,000 binucleated cells scored/ subject | Routine formaldehyde monitoring by factory; Range of geometric means (mg/m^3^):; Exposed: 0.06–0.25; Unexposed: 0.01; Cumulative dose (mg/m^3^-year) determined for each worker (C × T). C = geometric mean of concentration for a year at a sampling site, T = years.; Exposed: 0.90 (0.60-1.78); Referent: 0.06 (0.02-0.10) | MN frequency (% per 1,000, 95% CI) in PBLs
| | Exposed | | | Referent
| | 3.05 ± 1.47 | | | 1.71 ± 0.96
| | Poisson regression models adjusted for age, gender, smoking habits
| | Micronucleus frequency (per 1,000, frequency ratio (FR)) in PBL)
| | CED (mg/m^3^-year) | | N | Exposed | FR (95% CI)
| | 0.01 – 0.06 | | 45 | 1.36 ± 0.86 | 1
| | 0.06 – 0.125 | | 55 | 1.87 ± 0.92 | 1.38 (1.00-1.91)
| | 0.125 – 0.9 | | 46 | 2.50 ± 1.17 | 1.83 (1.34-2.52)
| | 0.9 – 3.75 | | 54 | 3.65 ± 1.40 | 2.67 (1.99-3.64)
| | Poisson regression models with adjustment for age, smoking status and alcohol use
Peteffi et al. (2015) Brazil; Prevalence study; Population: 46 workers in furniture manaufacturing facility (mean age 34.5 year, 56.5% male, 1 smoker) and unexposed group (n = 45) recruited from employees and students of local university with no history of occupational exposure to potentially genotoxic agents or substances metabolized to formic acid. (mean age 35.4 year, 33.3% male, 0 smokers); Outcome: Oral buccal epithelial cell samples (scraped with endocervical brush), micronucleus test, DNA-specific Feulgen staining and counterstaining with Fast Green according to Tolbert et al. (1992); analyzed 2,000 cells/ person by 2 independent observers (1,000 ea). | Monitoring in 7 sections in facility; referent monitoring in 5 areas of university; breathing zone 8 hr samples collected on same day as biological samples. Urine samples collected at end of work day on 5^th^ day of work; correlation of formaldehyde concentration in air with urinary formic acid concentration, r = 0.626, p <0.001; UV painting, lamination/press, packaging, edge lamination 0.03–0.04 ppm (0.037–0.05 mg/m^3^); Edge painting, machining and drilling center, board cutting 0.06–0.09 ppm (0.07–0.11 mg/m^3^)); Referent mean (SD) 0.012 (0.008) ppm (0.015 (0.01) mg/m^3^); Formic acid median; Exposed 20.47 mg/L; Referent 4.57 mg/L; Exposure duration 5.76 year | Comparisons of micronucleus frequency and other DNA damage in buccal cells, median (interquartile range)
| | | | Referent | Exposed | p-Value
| | Micronuclei | | 0 | 0 | 0.08
| | Nuclear buds | | 0 (0–0.50) | 0.24 (0–0.63) | 0.126
| | Binucleated cells | | 0.50 (0–1.38) | 1.34 (0.64–2.38) | 0.003
| | Karyorrhexis | | 1.0 (0.49–2.04) | 1.31 (0.58–2.49) | 0.372
| | Nonparametric tests used because data were not normally distributed. Exposed and referent compared using Mann-Whitney test.; No differences between men and women for measures of DNA damage in either exposed or referent.; No correlation between urinary formic acid and measures of DNA damage.
Souza and Devi (2014) India; Prevalence study; Population: 30 male workers in anatomy departments (embalming) in several medical colleges (mean age 39.9 year, 50% smokers); compared to 30 male clerical workers in same facilities (mean age 37.8 year, 30% smokers).; Outcome: Total MN/ 1,000 cells in peripheral lymphocytes. Assays conducted blinded. Cytokinesis -blocked micronucleus assay Costa et al. (2008), 1,000 binucleated cells/ subject. | No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | MN frequency in Lymphocytes by Exposure Group (mean (SD))
| No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | | | Mean ± SD | | 95% CI
| No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | Exposed (N = 30) | | 9.5 ± 3.23 | | 8.29–10.7
| No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | Comparison group (N = 30) | | 3.73 ± 1.43 | | 3.19–4.26
| No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | Difference in means^a^ | | 5.76 | | 4.47–7.06^a^
| No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | ^a^No difference = 0.
| No measurements reported.; Duration exposure mean 10.66 year, range 1–30 year | Association of MN frequency with exposure and smoking evaluated using two-way ANOVA. Smoking was not associated with MN frequency.; Pearson’s correlation test showed a positive correlation (r = 0.5, P = 0.02) between the duration of exposure and the frequency of MN in lymphocytes.
Bouraoui et al. (2013) Tunisia; Prevalence study; Population: 31 pathology workers (60% female, mean age 42, 9.6% smokers) compared to 31 unexposed administrative staff in same facility (60% female, mean age 43 year, 12.9% smokers).; Outcome: MN peripheral lymphocytes: Cytokinesis-blocked MN assay in combination with FISH using all-chromosome centromeric probe Sari-Minodier et al. (2002); stain 5% Giemsa, 2,000 binucleated cells scored/ subject, Fenech (2000), blinding not described | Exposure assessed by job title and duration of employment. Atmospheric air sampling performed in area of potential exposure; Concentration:; Means of 3 samplings:; 0.25 mg/m^3^; 2.21 mg/m^3^; 4.2 mg/m^3^; Duration:; Mean 15.68 years (6.53 ± 0.7 hrs/d) | MN frequency in peripheral lymphocytes (Mean ± SD)
| | | | Referent | | Exposed
| | MN (%/1,000 binucleated cells) | | 7.08 ± 4.62 | | 25.35 ± 6.28*
| | FISH MN (%/2,000 cells) | | 6.12 ± 4.24 | | 23.25 ± 5.92*
| | C + MN | | 4.03 ± 3.64 | | 18.38 ± 5.94*
| | C − MN | | 2.09 ± 0.74 | | 4.87 ± 3.22
| | C1+ MN | | 2.93 ± 2.74 | | 15.35 ± 6.03*
| | Cx + MN | | 1.1 ± 1.16 | | 3.03 ± 2.7*
| | *p <0.05, Student’s t-test
| | Duration of exposure was associated with all of the cytogenetic alterations.; Abbreviations: C +, C −, C1 + MN, Cx + MN
Costa et al. (2013) Portugal; Prevalence study; Population: 35 pathology workers from 4 hospital laboratories, exposed to formaldehyde for at least 1 year (88.6% female, mean age 41.2 year, 20% smokers), compared to 35 unexposed employees from same work area (80% female, mean age 39.8 year, 20% smokers).; Outcome: MN in peripheral lymphocytes, samples collected between 10 & 11 am. Cytokinesis-blocked MN test Teixeira et al. (2004). 1,000 cells analyzed/ subject, MN per 1,000 binucleated cells, scored blindly by one reader, criteria Fenech (2007); Related references: Costa et al. (2008); Costa et al. (2011) | Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure conc.:; Mean 0.44 mg/m^3^, range 0.28–0.85 mg/m^3^; Exposure duration 12.5 ± 8.1 years, range 1–30 year | Univariate analyses presented in Figure 1 of the paper. MN frequency was 2.5-fold higher in exposed group compared to referent group.
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure conc.:; Mean 0.44 mg/m^3^, range 0.28–0.85 mg/m^3^; Exposure duration 12.5 ± 8.1 years, range 1–30 year | MN frequency (%) in peripheral lymphocytes, exposed relative to referent group
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure conc.:; Mean 0.44 mg/m^3^, range 0.28–0.85 mg/m^3^; Exposure duration 12.5 ± 8.1 years, range 1–30 year | | | Ratio | | 95% CI
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure conc.:; Mean 0.44 mg/m^3^, range 0.28–0.85 mg/m^3^; Exposure duration 12.5 ± 8.1 years, range 1–30 year | Exposure | | 2.1 | | 1.025–3.174
| Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure conc.:; Mean 0.44 mg/m^3^, range 0.28–0.85 mg/m^3^; Exposure duration 12.5 ± 8.1 years, range 1–30 year | Multivariate analysis, adjusted for gender, smoking and age
Lin et al. (2013) China; Prevalence study; Population: 96 plywood workers exposed to formaldehyde (13.5% female, mean age 33 year, 30.2% smokers) compared to referent group (N = 82) (4% female, mean age 31 year, 40% smokers).; Outcome: MN assay in peripheral lymphocytes, analyzed 1,000 binucleated cells/ subject, scoring criteria Fenech (1993), Fenech et al. (2003), blinded analysis MN assessed by exposure group and # years worked. | Personal air monitoring and job assignment.; Average concentration:; High, N = 38 (making glue): 1.48 mg/m^3^, range 0.914–2.044 mg/m^3^; Low, N = 58 (sanding boards, pressing wood scraps with glue at high temp): 0.68 mg/m^3^, range 0.455–0.792 mg/m^3^; Referent group, N = 82 (grinding wood scraps): 0.13 mg/m^3^, range 0.019–0.252 mg/m^3^; Exposure duration: 2.52 years | MN Frequency in peripheral lymphocytes by formaldehyde exposure level and work years
| | By Exposure levels
| | | | Referent | Low | High
| | MN freq (%) | | 2.05 ± 1.72 | 2.02 ± 1.81 | 2.37 ± 1.79
| | ANOVA p-value = 0.455; Poisson regression p-value = 0.288
| | Number of Work Years
| | | | <1 (N= 57) | 1–3 (N= 64) | >3 (N= 57)
| | MN freq (%) | | 1.02 ± 1.10 | 2.25 ± 1.56* | 2.90 ± 1.96*
| | ANOVA p-value < 0.001; Poisson regression p-value < 0.001
| | ANOVA and Poisson regression adjusting for age, gender, smoking status, alcohol, duration of employment
Costa et al. (2011) Portugal; Prevalence study; Population: 48 pathology workers from 5 hospital laboratories, exposed for at least 1 year (28% female, mean age 40 year, 21% smokers), compared to 50 unexposed employees matched by age, gender, lifestyle, smoking habits and work area (25% female, mean age 37 year, 14% smokers).; Outcome: MN in peripheral blood lymphocytes, (Teixeira et al., 2004); stain 4% Giemsa; scored 1,000 binucleated cells/ subject, scored blind by one reader, criteria Fenech (2007) | Exposure assessed via air sampling in breathing zone and deriving an 8-hr TWA for each subject.; Concentration:; Mean: 0.53 mg/m^3^, range 0.05–1.94 mg/m^3^; Duration:; Mean: 13.6 years, range: 1–31 years | MN frequency (%) in peripheral lymphocytes
| | | | Referent | | Exposed
| | MN | | 3.66 ± 0.51 | | 6.19 ± 0.62*
| | *p <0.05; Mann-Whitney U test and Kruskal-Wallis test
Ladeira et al. (2011) Portugal; Prevalence study; Population: 56 hospital workers in histopathology labs (66% female, mean age 39.5 years, 19.6% smokers) compared to 85 administrative staff (64% female, mean age 32.4 years, 29.4% smokers).; Outcome: MN in peripheral lymphocytes and buccal cells. Samples coded and analyzed blinded. Lymphocytes, cytokinesis-block micronucleus cytome assay, stain May-Grunwald-Giemsa, 1,000 binucleated cells scored/ subject by 2 readers; buccal mucosa cells, stain Feulgen, 2,000 cells scored/ subject, 2 readers; Related references: Viegas et al. (2010); Speit et al. (2012) | Personal air sampling, 6–8 hrs, estimated 8-hr TWA; Exposure conc.:; Mean TWA 8 hr 0.2 ± 0.14 mg/m^3^; Mean ceiling value: 1.4 ± 0.91 mg/m^3^, range 0.22–3.6 mg/m^3^; Exposure duration: 14.5 (1–33) years | MN frequency (Mean ± SD) by cell type
| | | | Lymphoctyes | | Buccal cells
| | Referent | | 0.81 ± 0.172 | | 0.16 ± 0.058
| | Exposed | | 3.96 ± 0.525* | | 0.96 ± 0.277*
| | OR^a^ | | 9.67 | | 3.99
| | 95% CI | | 3.81–24.52 | | 1.38–11.58
| | *p≤0.002, Mann-Whitney test; ^a^Odds ratio for risk of presence of MN; binary logistic regression
| | MN frequency (Mean ± SD) by years of exposure
| | Years | | N | Lymphocytes | Buccal cells
| | <5 | | 8 | 2.75 ± 0.940 | 0.63 ± 0.625
| | 6–10 | | 19 | 3.05 ± 0.775 | 0.63 ± 0.326
| | 11–20 | | 12 | 5.50 ± 1.317 | 0.83 ± 0.458
| | >21 | | 15 | 5.00 ± 1.151 | 1.20 ± 0.8
| | Evaluated potential confounding by age, gender, smoking and alcohol, no major evidence of confounding noted
Jiang et al. (2010) China; Prevalence; Population: 151 male workers from 2 plywood plants (mean age 27.4 years, 52.3% smokers) compared to 112 unexposed workers at a machine manufacturer in same town (mean age 28.7 years, 42.9% smokers).; Outcome: Cytokinesis-block micronucleus (CB-MN), Fenech (1993), scoring criteria Fenech et al. (2003), 1,000 binucleated lymphocytes/ subject, blinded analysis | Exposure assessed by job title and personal air monitoring.; Exposure concentration ppm converted to mg/m^3^ by EPA.; Exposed:; 1.08 mg/m^3^, range 0.1–7.75 mg/m^3^; Referent: <0.01 mg/m^3^ (LOD); Duration:; Mean 2.51 years; Range: (0.5–25) years | Lymphocyte MN frequency by duration and formaldehyde concentration
| | Duration (years) | | MN^a^ | Conc. (mg/m^3^) | MN^b^
| | 0.6–1 | | 4.33 ± 2.81 | 0.0123^c^ | 2.67 ± 1.32
| | 1–3 | | 5.84 ± 3.63 | 0.1353 | 4.03 ± 2.40
| | 3–25 | | 5.84 ± 3.24* | 0.3444 | 5.74 ± 3.13*
| | | | | 0.4797 | 6.76 ± 3.81*
| | | | | 3.1488 | 8.25 + 3.53*
| | ^a^ANOVA, Dunnett-Hsu test, p =0.04, adjusted for age, formaldehyde concentration, current smoking status, alcohol
| | ^b^ANOVA, p <0.05; Trend p <0.001
| | ^c^Referent group
Viegas et al. (2010) Portugal; Prevalence study; Population: 30 formaldehyde factory workers and 50 pathology/anatomy lab workers exposed for >1 year (40% female, mean age 35.7 year, 31.3% smokers), compared to 85 unexposed individuals (63.5% female, mean age 33.9 year, 30.6% smokers); Outcome: MN assay, buccal mucosa cells and peripheral lymphocytes. Blinded coding and analysis, Buccal cells, Feulgen stain, 2,000 cells scored/ subject by 4 observers, scoring criteria Tolbert et al. (1992), peripheral lymphocytes, stain May-Grunwald-Giemsa, 1,000 binucleated cells scored/ subject; Also discussed in Viegas et al. (2013) | Personal air sampling, (N = 2 in factory, N = 29 in labs); 6–8 hrs, estimated 8-hr TWA Exposure duration:; Factory workers: 6.2 (1–27) year; Lab workers: 14.5 (1–33) year; 8-hr TWA Concentration in:; Factory: 0.26 mg/m^3^, range 0.25–0.27 mg/m^3^; Lab: 0.34 mg/m^3^, range 0.06–0.63 mg/m^3^; Ceiling Concentrations; Factory: 0.64 mg/m^3^, range 0.004–1.28 mg/m^3^; Lab: 3.1 mg/m^3^, range 0.03–6.18 mg/m^3^ | MN Frequency by cell type (mean ± SD)
| | | | Referent | Factory | Laboratory
| | Peripheral lymphocytes | | 1.17 ± 1.95 | 1.76 ± 2.07 | 3.7 ± 3.86*
| | Buccal cells | | 0.13 ± 0.48 | 1.27 ± 1.55* | 0.64 ± 1.74*
| | *p <0.01, Spearman’s correlation test
| | Years of exposure correlated with MN in peripheral lymphocytes (r = 0.401, p <0.01), and MN in buccal cells (r = 0.209, p = 0.008); Spearman’s test; No correlation between MN frequency and smoking or gender, small magnitude of correlation with age (r = +0.194; p <0.05 for blood lymphocytes, r = −0.168; p <0.05 for buccal cells).
Costa et al. (2008) Portugal; Prevalence study; Population: 30 pathology lab workers (4 hospitals), (70% female, mean age 38 year, 27% smokers) compared to 30 administrative employees matched by age, gender, lifestyle, smoking habits, and work area (63.3% female, mean age 37 years, 23% smokers).; Outcome: MN in peripheral lymphocytes (Teixeira et al., 2004), stain 4% Giemsa; scored 1,000 binucleated cells/ subject, scored blind by one reader, criteria Caria et al. (1995) | Air sampling in breathing zone, derived an 8-hr TWA for each subject; Concentration:; Mean: 0.54 mg/m^3^, range: 0.05–1.94 mg/m^3^; Duration: 11 years; Range: (0.5–27) years | MN frequency in peripheral lymphocytes
| Air sampling in breathing zone, derived an 8-hr TWA for each subject; Concentration:; Mean: 0.54 mg/m^3^, range: 0.05–1.94 mg/m^3^; Duration: 11 years; Range: (0.5–27) years | | | Referent | | Exposed
| Air sampling in breathing zone, derived an 8-hr TWA for each subject; Concentration:; Mean: 0.54 mg/m^3^, range: 0.05–1.94 mg/m^3^; Duration: 11 years; Range: (0.5–27) years | Lymphocyte MN | | 3.27 ± 0.69 | | 5.47 ± 0.76*
| Air sampling in breathing zone, derived an 8-hr TWA for each subject; Concentration:; Mean: 0.54 mg/m^3^, range: 0.05–1.94 mg/m^3^; Duration: 11 years; Range: (0.5–27) years | P=0.003, Mann-Whitney U-test and Kruskal-Wallis test. Authors reported positive correlation between formaldehyde exposure levels and MN frequency (r=0.384, p=0.001)
Pala et al. (2008) Italy; Prevalence study; Population: 36 lab workers (66.7% female, mean age 40.1 year, 16.7% smokers); Outcome: Peripheral lymphocytes (blood sampled at end of 8-hour shift), analysis blind to exposure. MN using modified cytokinesis-blocked method, Fenech and Morley (1986); stain 3% Giemsa, 2,000 cells/ subject | Personal air monitoring (8-hr sample);; Exposure categories:; High: ≥ 0.026 mg/m^3^, Low: < 0.026 mg/m^3^; Mean concentration:; Low (n = 25): 0.015 mg/m^3^ (range 0.005–0.0254); High (n = 9): 0.056 mg/m^3^ (range 0.026–0.269); Duration of exposure: NR | Micronuclei Frequency by Exposure Level (mean ± SD)
| | | | <0.026 mg/m^3^ | | ≥0.026 mg/m^3^
| | MN | | 0.26 ± 0.24 | | 0.31 ± 0.17
| | Means ratio (95% CI) 1.43 (0.26–7.81), Poisson regression adjusted for gender, age, smoking and other exposures
Orsiere et al. (2006) France; Prevalence; Population: 59 hospital pathology workers from 5 labs (81% female, mean age 44.7 year, 20% smokers) compared to 37 unexposed workers (76% female, mean age 44 year, 24% smokers).; Outcome: MN in peripheral lymphocytes. Subgroups selected randomly from initial groups. Assays conducted blinded. Cytokinesis-blocked micronucleus assay Sari-Minodier et al. (2002); stain 5% Giemsa, scoring criteria Fenech (2000), 1,000 binucleated cells/ subject; FISH with a pan-centromeric DNA probe, same operator scored exposed and referent blinded; Related reference: Iarmarcovai et al. (2006). | Personal sampling; Short-term: 15 min, Long-term 8 hrs during typical work-day.; Concentration^1^:; Mean 15-min: 2.46 mg/m^3^, range <0.12–25. 1 mg/m^3^; Mean 8-hour 0.123 (range <0.123–0.86 mg/m^3^; Duration exposure 13.2 years, range 0.5–34 years | Binucleated micronucleated cell rate (BMCR) in peripheral lymphocytes (mean ± SD)
| | | | Unexposed (n=37) | | Exposed (n=59)
| | % BMCR | | 11.1 ± 6.0 | | 16.9 ± 9.3*
| | *Number BMCR per 1,000 binucleated cells, p<0.05, Mann-Whitney U-test.
| | Linear regression of BMCR, increase of 0.263 per 1,000 binucleated cells in exposed, p =0.003, adjusting for gender, age, smoking and alcohol.
| | FISH Analysis of MN in peripheral lymphocytes by exposure (mean ± SD)
| | FISH Results^1^ | | Unexposed (n= 18) | Exposed (n = 18) | p-Value
| | % BMCR | | 11.9 ± 5.6 | 19.1 ±10.1 | 0.021
| | % MN | | 14.4 ± 8.1 | 21.0 ± 12.6 | 0.084
| | C + MN (%) | | 10.3 ± 7.1 | 17.3 ± 11.5 | 0.059
| | C − MN (%) | | 4.1 ± 2.7 | 3.7 ± 4.2 | 0.338
| | C1 + MN (%) | | 3.1 ± 2.4 | 11.0 ± 6.2 | p<0.001
| | Cx + MN (%) | | 7.8 ± 5.5 | 6.3 ± 6.3 | 0.163
| | ^1^Results expressed as frequency per 1,000 binucleated cells, mean ± SD; analyzed using Mann-Whitney U-test
| | Linear regression of C1 + MN, increase of 0.586 MN containing one centromere per 1,000 binucleated cells in exposed, <0.001, adjusting for gender, age, smoking and alcohol
Ye et al. (2005) China; Prevalence study; Population: 18 workers at a formaldehyde plant at least 1 year (38.9% female, mean age 29 year, and 16 workers exposed to indoor air formaldehyde via building materials (75% female, mean age 22 year) compared to 23 students with no known source of formaldehyde exposure (dormitories) (48% female, mean age 19 year); all nonsmokers; Outcome: MN in nasal cells, stain Wright’s, scoring criteria Fenech et al. (2003), per 3,000 cells, blinding not stated. | Formaldehyde sampling:; TWA Concentration; Controls; 0.011 ± 0.0025 mg/m^3^; Max. 0.015 mg/m^3^; Wait staff; 0.107 ± 0.067 mg/m^3^; Max. 0.30 mg/m^3^; Workers; 0.985 ± 0.286 mg/m^3^; Max. 1.694 mg/m^3^; Exposure duration:; Workers 8.5 (1–15) years; Waiters 12 wks | MN frequency in nasal cells
| | | | Referent | Wait Staff | HCHO Workers
| | MN | | 1.25 ± 0.65 | 1.75 ± 1.00 | 2.70 ± 1.50*
| | P <0.05, one-way ANOVA, values estimated from figure
Burgaz et al. (2002) Turkey; Prevalence study; Population: 28 pathology workers (46.4% female, mean age 29.7 year, 43% smokers) and 18 unexposed male employees (mean age 31.1 year, 25% smokers), may overlap with study population from Burgaz et al. (2001) Outcome: MN frequency in buccal mucosal cells, stain Feulgen’s reaction plus Fast Green, MN, 3,000 cells/ subject counted, coded slides, scoring criteria Tolbert et al. (1992); Sarto et al. (1987) | Concentration:; Range:2.46–4.92 mg/m^3^; Duration: 4.7 ± 3.33 (1–13) years | MN frequency (%) in buccal mucosal cells (mean ± SD)
| Concentration:; Range:2.46–4.92 mg/m^3^; Duration: 4.7 ± 3.33 (1–13) years | | | Referent | | Exposed
| Concentration:; Range:2.46–4.92 mg/m^3^; Duration: 4.7 ± 3.33 (1–13) years | MNF Frequency | | 0.33 ± 0.30 | | 0.71 ± 0.56*
| Concentration:; Range:2.46–4.92 mg/m^3^; Duration: 4.7 ± 3.33 (1–13) years | *p <0.05, multifactorial ANOVA adjusting for age, smoking, and gender
| Concentration:; Range:2.46–4.92 mg/m^3^; Duration: 4.7 ± 3.33 (1–13) years | MN frequency was not associated with duration of exposure
Burgaz et al. (2001) Turkey; Prevalence study; Population: 23 pathology workers (12 male, 11 female) occupationally exposed 5 d, 8 hrs/ wk, mean age 30.6 year, 39% smokers compared to 25 male university and hospital staff, mean age 35.4 year, 76% smokers; Outcome: MN frequency in nasal cells. Previously coded slides, stain Feulgen’s reaction plus Fast Green, MN, 3,000 cells/ subject counted, scoring criteria Tolbert et al. (1992); Sarto et al. (1987) | Exposure based on occupation and duration of employment and quantified via stationary air monitors; Exposure conc.: 2.46–4.92 mg/m^3^ (converted from ppm by EPA); Exposure duration:; Mean: 5.06 ± 3.47 years; Range: (1–13) years | MN frequency (%) in nasal epithelial cells (mean ± SD)
| | | | Referent | | Exposed
| | MN frequency | | 0.61 ± 0.27 | | 1.01 ± 0.62*
| | *p <0.05, nonparametric test
| | MN frequency was not associated with duration of exposure. MN frequency higher in male exposed, similar between smokers and nonsmokers in referent.
He et al. (1998) China; Prevalence study; Population: 13 anatomy students exposed during a 12-wk course (10 hr/ wk) compared to 10 students from same school. Age and gender similar between groups, all non-smokers.; Outcome: MN assay, Fenech and Morley (1985), scored 1,000 cells per individual, blinding not described | Breathing zone air samples during dissection.; Measurements limited to location of exposed students.; Concentration in breathing zone: Mean 3.17 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | MN frequency (%) in peripheral blood lymphocytes (mean ± SD)
| Breathing zone air samples during dissection.; Measurements limited to location of exposed students.; Concentration in breathing zone: Mean 3.17 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | | | Referent | | Exposed
| Breathing zone air samples during dissection.; Measurements limited to location of exposed students.; Concentration in breathing zone: Mean 3.17 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | Lymphocyte MN | | 3.15 ± 1.46 | | 6.38 ± 2.50*
| Breathing zone air samples during dissection.; Measurements limited to location of exposed students.; Concentration in breathing zone: Mean 3.17 mg/m^3^; Duration:; 12 wks (10 hrs/wk) | *p <0.01, analytic test not described
Kitaeva et al. (1996) Russia; Prevalence study; Population: anatomy instructors (8 female, 5 male), mean age 41 year) compared to 6 female unexposed (mean age 28.5 year); students (6 female, 6 male); Outcome: MN in buccal cells, 1994–1995. MN in mucosal cells compared between exposed and referent instructors, and before and after a 40-min exposure for students at 24 and 48 hrs. Blinding not described, stain Feulgen and light green, analyzed 2,000 cell/ subject | No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | MN frequency (%) in buccal mucosa cells
| No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | | | Referent | Exposed
| No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | Female instructors | | 0.64 (N=6) | 2.94* (N=8)
| No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | | | Before | 24 Hr Post | 48 Hr Post
| No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | Female students | | 0.58 | 2.50** | 2.64**
| No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | Male students | | 0.77 | 2.02* | 1.86
| No quantitative exposure assessment.; Duration of employment among instructors, females 23.6 years; males 25.6 years; 40-min exposures | Male instructors, no Referent (MN frequency = 1.18%) *p <0.05, **p <0.01, Student’s t-test
Ballarin et al. (1992) Italy; Prevalence study; Population: 15 plywood factory workers (46.7% female, mean age 31 years,) compared to 15 university or hospital clerks matched for age and sex (mean age 31 year). All nonsmokers.; Outcome: MN in nasal mucosal cells, stain feulgen’s plus Fast Green, analysis blinded by one reader, 6,000 cells/ subject, scoring criteria Sarto et al. (1987). | Personal sampling; 8-hr TWA (NIOSH, 1977); Warehouse (N = 3) 0.39 ± 0.20 mg/m^3^, range 0.21–0.6 mg/m^3^; Shearing-press (N = 8) 0.1 ± 0.02 mg/m^3^, range 0.08–0.14 mg/m^3^; Sawmill (N = 1), 0.09 mg/m^3^; Inspirable wood dust: 0.11–0.69 mg/m^3^, 0.73 in sawmill; Employment duration 6.8 years | Mean frequency micronuclei per 1000 cells in nasal mucosal cells by exposure group
| | | | Referent | | Exposed
| | MN (%) (SD) | | 0.25 (0.22) | | 0.9 (0.47)*
| | *p <0.01, Mann-Whitney U test
Short-term Studies
Lin et al. (2013) China; Cross-shift change; Population: 62 plywood workers (17.7% female, mean age 34 year, 17.7% smokers); Outcome: Peripheral lymphocytes, cytokinesis-block micronucleus assay, Fenech (1993), analyzed 1,000 binucleated cells/ subject, scoring criteria Fenech (1993), Fenech et al. (2003); blinded analysis | Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^, range: 0.012–0.67 mg/m^3^; Mean exposure duration 2.53 ± 2 year | Frequency micronuclei in binucleated cells in peripheral lymphocytes
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^, range: 0.012–0.67 mg/m^3^; Mean exposure duration 2.53 ± 2 year | | | Before exposure | | After exposure
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^, range: 0.012–0.67 mg/m^3^; Mean exposure duration 2.53 ± 2 year | MN (%) | | 2.29 ± 1.21 | | 2.29 ± 1.65
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^, range: 0.012–0.67 mg/m^3^; Mean exposure duration 2.53 ± 2 year | p = 0.754, paired Wilcoxon test
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^, range: 0.012–0.67 mg/m^3^; Mean exposure duration 2.53 ± 2 year | Regression coefficients for formaldehyde level, before shift 0.73 (−0.46, 1.92); after shift −0.01 (−1.38, 1.35); Poisson regression adjusted for age, gender, smoking, and alcohol
Ying et al. (1997) China; Panel study; Population: 25 non-smoking anatomy students (13 males, 12 females, mean age 18.8 year, Han nationality) exposed during 8-wk course, 3-hr session, 3 times/ wk.; Outcome: MN Nasal and Buccal cells, assessed before the start of the course and at the end of 8-wk period. Blinded analysis, one observer; Wright’s stain, scored 4,000 cells/ subject; MN blood lymphocytes, stain 4% Giemsa, scored mean of 2870–3167 cells/ subject; MN scoring criteria Sarto et al. (1987) | Air sampling, estimated TWA and peak levels during class and in the dorms.; Anatomy labs:; Mean TWA: 0.51 ± 0.299 mg/m^3^, range: 0.07–1.28 mg/m^3^; Dormitories:; Mean TWA: 0.012 ± 0.003 mg/m^3^, range: 0.011–0.016 mg/m^3^; Duration: 8 wks | Micronucleated Cell Frequency (Mean+SEM), Change over 8 weeks
| | | | Before exposure | | After exposure
| | Oral Mucosa | | 0.57 ± 0.32 | | 0.86 ± 0.56*
| | Nasal Mucosa | | 1.20 ± 0.67 | | 3.84 ± 1.48*
| | Lymphocytes | | 0.91 ± 0.39 | | 1.11 ± 1.54
| | *p <0.01, paired t-test
Titenko-Holland et al. (1996) USA; Panel study; Population: same subjects as in Suruda et al. (1993); 35 mortuary students intermittently exposed for 90 d (28 students (with adequate samples, 22 males, 6 females)), age 20–33 years.; Outcome: MN analysis on buccal and nasal cells using FISH; blinded analysis; Related study: Suruda et al. (1993), same subjects | See Suruda et al. (1993); Subjects with complete MN data from buccal mucosa cells (n = 19):; Lagged (7–10 d before the last sampling): 1.2 ± 2.1 ppm-hrs;; 90-d cumulative (90 d): 14.8 ± 7.2 ppm-hrs;; Subjects with complete MN data from nasal cells (n = 13):; Lagged (7–10 d): 1.9 ± 2.5 ppm-hrs;; 90-d cumulative (90 d): 16.5 ± 5.8 ppm-hrs | Micronuclei before and after embalming class (per 1,000 cells) by cell type
| | | | Preexposure | | Postexposure
| | Buccal Cells (N = 19)
| | MN Total | | 0.6 ± 0.5 | | 2.0 ± 2.0*
| | MN^+^ | | 0.4 ± 0.4 | | 1.1 ± 1.3
| | MN^−^ | | 0.1 ± 0.2 | | 0.9 ± 1.1*
| | Nasal Cells (N = 13)
| | MN Total | | 2.0 ± 1.3 | | 2.5 ± 1.3
| | MN^+^ | | 1.2 ± 1.3 | | 1.0 ± 0.8
| | MN^−^ | | 0.5 ± 0.5 | | 1.0 ± 0.6*
| | *p <0.05, Wilcoxon sign-rank test, two-tailed
| | Association with 90-d cumulative exposure for change in total MN frequency in buccal cells, r =0.44, p =0.06; no association with 7–10 d lagged exposure, Spearman rank order correlation
Suruda et al. (1993) USA; Panel study; Population: 29 students (with adequate samples) (24.1% female, mean age 23.6 year, 17.2% smokers) exposed to formaldehyde for 9 wks during embalming course, with baseline samples taken. Mean duration of embalming 125 min. Possible exposure prior to course.; Outcome: MN assay, nasal, buccal and micronucleated peripheral blood lymphocytes. Analysis blinded to exposure status; MN assay buccal and nasal cells, Stich et al. (1982), stain Feulgen/ Fast Green, 1,500 cell/ subject; MN lymphocytes Fenech and Morley (1985), stain Feulgen 2,000 cells/ subject | Personal sampling for 121 of 144 embalmings; cumulative exposure estimated using sampling data and time-activity data; Continuous area samples over embalming tables for short-term peaks; Concentration^1^:; Mean: 1.72 mg/m^3^, range 0.18–5.29 mg/m^3^; Duration: 9 wks; Average cumulative exposure 18.2 mg/m^3^–hr, range 5.3–41.3 mg/m^3^-hr 8-hr TWA Mean 0.41 mg/m^3^, range 0.123–1.2 mg/m^3^; Measurements of glutaraldehyde, phenol, & methanol all < LOD, isopropyl alcohol < LOD or very low. | Micronuclei before and after embalming class (per 1,000 cells)
| | Cell type | | Before exposure | | After 9 weeks
| | Buccal | | 0.046 ± 0.17 | | 0.60 ± 1.27*
| | Nasal | | 0.41 ± 0.52 | | 0.50 ± 0.67
| | Micronucleated lymphocytes | | 4.95 ± 1.72 | | 6.36 ± 2.03*
| | *p <0.05, Wilcoxon sign-rank test
| | Buccal MN in males associated with cumulative exposure, Spearman coefficient, not nasal MN or micronucleated lymphocytes
Zeller et al. (2011) Germany; Controlled human exposure study; Subjects: 41 healthy volunteers exposed 4 hr/d for 5 d, all male, nonsmokers; Outcome: MN in peripheral blood lymphocytes and nasal mucosa cells assessed before and after exposure. Lymphocytes: CBMN test, scored 1,000 binucleated cells/subject on coded slides. Nuclear division index (NDI) = # cells with 1–4 micronuclei/ Total cells scored. Nasal cells: scored 2,000 cells/ subject on coded slides. Difference in means analyzed using Cochran Mantel Haentzel test and ANOVA. | 12 groups of 2 to 4 persons in a chamber, exposures randomly assigned.; Formaldehyde concentrations: 0 (i.e., background level of 0.01 ppm); 0.3 ppm (0.37 mg/m^3^)^a^ with four peaks of 0.6 ppm (0.74 mg/m^3^); 0.4 ppm (0.49 mg/m^3^) with 4 peaks of 0.8 ppm (0.98 mg/m^3^); 0.5 ppm (0.67 mg/m^3^); and 0.7 ppm (0.86 mg/m^3^); Peaks were 15 min each,; Four 15-min exercise sessions during exposure. | Frequency of micronuclei and NDI in lymphocytes and nasal mucosa before and after 4-hr exposure over 5 d (N = 40)
| | | | Cells with micronuclei/1,000 | | Nuclear Division Index
| | Lymphocytes
| | Before | | 6.5 ± 3.226 | | 2.0 ± 0.232
| | After | | 5.7 ± 3.339^a^ | | 2.0 ± 0.176
| | Nasal mucosa^b^
| | Before | | 0.21 ± 0.35
| | After | | 0.27 ± 0.42
| | 1-wk after | | 0.24 ± 0.43
| | 2-wks after | | 0.24 ± 0.45
| | 3-wks after | | 0.17 ± 0.41
| | ^a^p = 0.11; ^b^Several slides could not be analyzed, hence only 1,000 cells scored for several individuals (9–13 subjects per sampling time).
Speit et al. (2007a) Germany; Controlled human exposure study; Subjects: 21 healthy volunteers exposed to formaldehyde for 4 hrs/d for 10 d, 11 males, nonsmokers, aged 19–36 years.; Outcome: MN in buccal mucosal cells assessed prior to controlled exposure and then during postexposure period. Blinded analysis at end of study by one person, stain DAPI/ propidium iodide, Analyzed 2,000 cells/ subject | Source: paraformaldehyde. Exposure duration:; 10 consecutive d, 5 groups of 3–6 persons in chamber, 4-hr exposures, some exposures masked with ethyl acetate (EA), 3 15-min exercise sessions during exposure.; Cumulative exposure 16.6 mg/m^3^ – hrs; Target concentrations: 0, 0.15, 0.3, 0.5, 0 + EA, 0.3 + EA, 0.5 + EA, 0.3 + 4 x 0.6, 0.5 + 4 x 1.0, and 0.4 + 4 x 1.0 + EA | MN Frequency (per 1,000 cells) in Buccal Mucosa, mean ± SD
| | | | Immediately before exposure | | End of 10-d exposure
| | Mean MN | | 0.86 ± 0.84 | | 1.33 ± 1.45
| | p = 0.052, Wilcoxon signed rank test
DNA Damage
Prevalence Studies
Zendehdel et al. (2017) Iran; Prevalence study; Population: Workers in 3 melamine dinnerware manufacturing workshops (n = 49) and referents matched by age and sex (n = 34) who worked in food industries, # smokers higher in referent (26% versus 16%), >90% male. Recruitment and participation were not described.; Outcome: Peripheral blood cells, Comet assay, alkaline conditions, according to Tice et al. (2000) blinding not described; minimum of 50 randomly selected cells per sample; tail moment and Olive moment | Personal air sampling, NIOSH method 3500, whole shift for each worker.; Median TWA in 3 workshops, 0.086 mg/m^3^; range, 0.02– 0.22 mg/m^3^; authors state that 2/3 of sample were exposed to < 0.1 mg/m^3^; Work duration:; Exposed 2.5 (1–22) years; Referent 2.0 (1–25) years | Comparison of DNA damage (comet assay) between exposed and referent
| | | | Olive moment Median (min-max) | | Tail moment Median (min-max)
| | Exposed (N = 49) | | 13 (7.4-36.7) | | 22.2 (12.3-65)
| | Referent (N = 34) | | 8.4 (6.4-31.7) | | 14.8 (6.4-57.7)
| | p value = 0.001; Mann-Whitney test
Costa et al. (2015) Portugal; Prevalence study; Population: 83 anatomy pathology workers from 9 hospital laboratories, exposed to formaldehyde for at least 1 year, compared to 87 unexposed employees from administrative offices in same geographic area. Exclusions: cancer history, radiation therapy or chemotherapy, surgery with anesthesia or blood transfusion in last year. Exposed and referent similar for mean age 39 years, 77% females, 25% smokers.; Outcome: Peripheral blood samples, coded, analyses blinded to exposure status.; Comet assay: alkaline conditions according to Singh et al. (1988); Scored blind 100 cells/ donor from two gels; % DNA in comet tail.; Exposed compared to unexposed using Student’s t-test for ln % tDNA; linear regression of ln %tDNA | Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.38 ppm (0.47 mg/m^3^); Range: 0.28–0.85 ppm (0.34-1.05 mg/m^3^); Exposure duration 12.0 ± 8.2 years | Comparison of % DNA in tail (comet assay) between exposed and referent
| | | | Mean | SD | Mean Ratio (95% CI)
| | Exposed (N = 83) | | 11.67^a^ | 0.72 | 1.5 (1.14–1.96)^b^
| | Referent (N = 87) | | 7.5 | 0.47 | 1.0
| | ^a^Student’s t-test, p<0.001.; ^b^model adjusted for age, gender, smoking habit, and fruit consumption (# pieces consumed/d).
Peteffi et al. (2015) Brazil; Prevalence study; Population: 46 workers in furniture manaufacturing facility (mean age 34.5 year, 56.5% male, 1 smoker) and unexposed group (n = 45) recruited from employees and students of local university with no history of occupational exposure to potentially genotoxic agents or substances metabolized to formic acid. (mean age 35.4 year, 33.3% male, 0 smokers); Outcome: Peripheral blood processed within 4 hr. Comet assay, alkaline conditions according to Tice et al. (2000); silver nitrate staining according to Nadin et al. (2001); 100 cells/ person read by two independent observers (50 cells each), classified by visual scoring according to Anderson et al. (1994); 5 categories based on tail migration (0–IV) and frequency of damaged cells (sum of I–IV), damage index (Pitarque et al., 1999) Nonparametric tests used because data were not normally distributed. Exposed and referent compared using Mann-hitney test | Monitoring in 7 sections in facility; referent monitoring in 5 areas of university; breathing zone 8 hr samples collected on same day as biological samples. Urine samples collected at end of work day on 5^th^ day of work; correlation of formaldehyde concentration in air with urinary formic acid concentration, r = 0.626, p<0.001; UV painting, lamination/press, packaging, edge lamination 0.03–0.04 ppm (0.037–0.05 mg/m^3^) Edge painting, machining and drilling center, board cutting 0.06–0.09 ppm (0.07–0.11 mg/m^3^)); Referent mean (SD) 0.012 (0.008) ppm (0.015 (0.01) mg/m^3^); Formic acid median; Exposed 20.47 mg/L; Referent 4.57 mg/L; Correlation formaldehyde concentration and formic acid r = −0.626, p <0.001; Exposure duration 5.76 year | Comparisons of DNA damage (comet assay) in peripheral blood cells, median (interquartile range)
| | | | Referent | Exposed | p-Value
| | Damage index | | 2.0 (0–4.0) | 6.5 (1.0–12.5) | 0.007
| | Damage frequency (%) | | 2.0 (0–4.0) | 6.0 (1.0–12.5) | 0.003
| | No differences between men and women for measures of DNA damage in either exposed or referent.; No correlation between urinary formic acid and measures of DNA damage.
(Aydın et al., 2013) Turkey; Prevalence study; Population: 46 male workers from 2 MDF plants (mean age 33.4 year, 39.1% smokers) compared to 46 non-exposed male workers in same area (mean age 38.4 year, 50% smokers) (administrative government offices and maintenance services). Half of workers used personal protective equipment.; Outcome: DNA damage, Comet assay, tail intensity, tail moment, and tail migration, alkaline conditions, 100 cells/ subject | 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | Comparison of Comet assay results in peripheral blood lymphocytes by exposure
| 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | | | Unexposed | | Exposed
| 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | Tail intensity | | 5.28 ± 0.22 | | 4.25 ± 0.29*
| 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | Tail moment | | 0.816 ± 0.002 | | 0.624 ± 0.003*
| 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | Tail migration | | 2.16 ± 0.007 | | 1.68 ± 0.005*
| 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | *ANOVA, P <0.05.
| 24 area samples in workplaces; personal samples in breathing zone over 8 hrs.; Mean: 0.25 ± 0.07 mg/m^3^; Range (0.12–0.41); Duration:; Mean: 7.3 years; Range (0.33–30) | Comparisons by smoking strata indicate similar pattern.
Lin et al. (2013) China; Prevalence study; Population: 96 plywood workers exposed to formaldehyde (13.5% female, mean age 33 year, 30.2% smokers) compared to referent group (N=82) (4% female, mean age 31 year, 40% smokers).; Outcome: Blood lymphocytes: DNA damage, Comet assay, olive tail moment, alkaline conditions (pH = 13), 50 cells/sample, blinded analysis. | Exposure assessed by air monitoring and job assignment.; Average concentration:; High Exposure, N=38 (making glue): 1.48 mg/m^3^ (0.914–2.044); Low exposure, N=58 (sanding boards, pressing wood scraps with glue at high temp): 0.68 mg/m^3^ (0.455–0.792); Referent group, N=82 (providing & grinding wood scraps): 0.13 mg/m^3^ (0.019–0.252); Exposure duration: 2.52 years | Comparison of Comet assay results in peripheral blood lymphocytes by exposure and duration of employment.
| | By Exposure
| | | | Referent | Low | High
| | Tail moment (Ln) | | 0.67 ± 0.55 | 0.88 ± 0.55* | 1.01 ± 0.56^*^
| | *ANOVA p-value = 0.006; linear regression model, trend p-value = 0.002, adjusted for age, gender, smoking status, alcohol consumption, duration of employment
| | By Number of Work Years
| | | | <1 (N= 57) | 1–3 (N = 64) | >3 (N = 57)
| | Tail moment (Ln) | | 0.76 ± 0.56 | 0.73 ± 0.59 | 0.99 ± 0.52
| | *ANOVA p-value = 0.131; trend p-value = 0.059, Adjusted for age, gender, smoking status, alcohol consumption, and formaldehyde levels
Gomaa et al. (2012) Egypt; Prevalence study; Population: 30 workers in pathology, histology and anatomy laboratories at a university (30% female, mean age 42.5 year) compared to 15 referents (46.7% female, mean age 39.3 year). Source of referent was not described.; Outcome: Comet assay, alkaline conditions according to Singh et al. (1988); tail length & tail moment; blinding not described; analyzed 50 cells per subject | No formaldehyde measurements; exposure defined by job type; Exposure duration: mean 14.3 year | Comparisons of Comet assay results by exposure
| No formaldehyde measurements; exposure defined by job type; Exposure duration: mean 14.3 year | | | Unexposed | | Exposed
| No formaldehyde measurements; exposure defined by job type; Exposure duration: mean 14.3 year | Tail length (mm) | | 12.5 ± 1.5 (7.2–14.7) | | 47.3 ± 8.5* (16.5–74.2)
| No formaldehyde measurements; exposure defined by job type; Exposure duration: mean 14.3 year | Tail moment | | 10.8 ± 1.2 (5.8–13.6) | | 56.1 ± 16.5* (11.4–88.1)
| No formaldehyde measurements; exposure defined by job type; Exposure duration: mean 14.3 year | *Student’s t-test, p <0.05; Mean value per 50 comets ± SE, distribution in parentheses.
| No formaldehyde measurements; exposure defined by job type; Exposure duration: mean 14.3 year | Results comparable between males and females.
Costa et al. (2011) Portugal; Prevalence study; Population: 48 pathology workers from 5 hospital laboratories, exposed for at least 1 year (28% female, mean age 40 year, 21% smokers), compared to 50 unexposed employees matched by age, gender, lifestyle, smoking habits, and work area (25% female, mean age 37 year, 14% smokers).; Outcome: DNA damage, comet assay, tail length and % tail DNA; alkaline conditions, 100 cells/ subject; analysis blind to exposure | Air sampling in breathing zone;; 8-hr TWA derived for each subject.; Concentration: ppm converted to mg/m^3^ by EPA.; Mean: 0.53 mg/m^3^; Range: (0.05–1.94); Duration:; Mean: 13.6 years; Range: (1–31) | Comparisons of Comet assay results by exposure
| Air sampling in breathing zone;; 8-hr TWA derived for each subject.; Concentration: ppm converted to mg/m^3^ by EPA.; Mean: 0.53 mg/m^3^; Range: (0.05–1.94); Duration:; Mean: 13.6 years; Range: (1–31) | | | Unexposed | | Exposed
| Air sampling in breathing zone;; 8-hr TWA derived for each subject.; Concentration: ppm converted to mg/m^3^ by EPA.; Mean: 0.53 mg/m^3^; Range: (0.05–1.94); Duration:; Mean: 13.6 years; Range: (1–31) | Tail length | | 42.00 ± 1.6 | | 54.55 ± 2.02*
| Air sampling in breathing zone;; 8-hr TWA derived for each subject.; Concentration: ppm converted to mg/m^3^ by EPA.; Mean: 0.53 mg/m^3^; Range: (0.05–1.94); Duration:; Mean: 13.6 years; Range: (1–31) | % DNA Tail | | 8.01 ± 0.64 | | 11.76 ± 0.74*
| Air sampling in breathing zone;; 8-hr TWA derived for each subject.; Concentration: ppm converted to mg/m^3^ by EPA.; Mean: 0.53 mg/m^3^; Range: (0.05–1.94); Duration:; Mean: 13.6 years; Range: (1–31) | ANOVA, Student’s t-test, p <0.05, compared to referent group. Tail length and % tail DNA did not vary by gender, age, or smoking. Comet assay parameters were not associated with exposure duration.
Jiang et al. (2010) China; Prevalence study; Population: 151 male workers from 2 plywood plants (mean age 27.4 year, 52.3% smokers) compared to 112 unexposed workers at a machine manufacturer in same town (mean age 28.7 year, 42.9% smokers).; Outcome: Peripheral blood lymphocytes, Comet assay, olive tail moment, alkaline conditions; blinded analysis, analyzed > 100 cells/ subject; Related reference: Yu et al. (2005) in Chinese | Exposure assessed by job title and personal air monitoring.; 4 exposure groups based on 8-hr TWA: 0.135, 0.344, 0.479, 3.141 mg/m^3^.; Concentration: ppm converted to mg/m^3^ by EPA.; Mean: 1.02 mg/m^3^; Range: (0.1–0.75); Duration:; Mean: 2.51 years; Range: (0.6–25) | Comparison of Comet assay results in peripheral blood lymphocytes by exposure and duration of employment
| | Ln tail moment (TM), geometric mean (95% CI)
| | Referent (n=112) | | | 0.93 (95%CI: 0.78–1.10)
| | 0.135 mg/m^3^ (n = 60) | | | 2.85 (95%CI: 2.37–3.43)*
| | 0.344 mg/m^3^ (n=35) | | | 3.01 (95%CI: 2.48–3.64)*
| | 0.479 mg/m^3^ (n=43) | | | 4.37 (95%CI: 3.78–5.05)*
| | 3.141 mg/m^3^ (n=13) | | | 8.86 (95%CI: 6.50–12.07)**
| | *TM compared to referent group, ANOVA, p<0.05;; **TM compared to referent and other exposure groups, ANOVA p<0.05
| | Tail moment by exposure history (years)*
| | 0.6–1 (n=33) | | | 2.27 (2.91–3.71)
| | 1–2 (n=68) | | | 2.69 (3.50–4.13)
| | 3–25 (n=50) | | | 3.53 (4.11–4.78)**
| | *ANOVA, p = 0.03, adjusted for age, formaldehyde exposure history and concentration, current smoking status, alcohol consumption; **Dunnett-Hsu test, compared to 0.6–1 year subgroup, p = 0.01
Costa et al. (2008) Portugal; Prevalence Study; Population: 30 pathology lab workers (4 hospitals), (70% female, mean age 38 year, 27% smokers) compared to 30 administrative employees matched by age, gender, lifestyle, smoking habits and work area (63.3% female, mean age 37 years, 23% smokers).; Outcome: Peripheral lymphocytes; blood samples collected 10–11 am; Scored blind to exposure status; Comet assay, tail length, alkaline conditions (pH = 13), 100 cells/ subject | Air sampling in breathing zone, 8-hr TWA derived for each subject; Mean: 0.54 mg/m^3^; Range: (0.05–1.94); Years employed:; Mean ± SD: 11 ± 7 years; Range: (0.5–27) | Comparisons of Comet assay results in peripheral blood lymphocytes by exposure
| Air sampling in breathing zone, 8-hr TWA derived for each subject; Mean: 0.54 mg/m^3^; Range: (0.05–1.94); Years employed:; Mean ± SD: 11 ± 7 years; Range: (0.5–27) | | | Unexposed | | Exposed
| Air sampling in breathing zone, 8-hr TWA derived for each subject; Mean: 0.54 mg/m^3^; Range: (0.05–1.94); Years employed:; Mean ± SD: 11 ± 7 years; Range: (0.5–27) | Tail Length | | 41.85 ± 1.97 | | 60.00 ± 2.31*
| Air sampling in breathing zone, 8-hr TWA derived for each subject; Mean: 0.54 mg/m^3^; Range: (0.05–1.94); Years employed:; Mean ± SD: 11 ± 7 years; Range: (0.5–27) | *p <0.05, Student’s t-test
| Air sampling in breathing zone, 8-hr TWA derived for each subject; Mean: 0.54 mg/m^3^; Range: (0.05–1.94); Years employed:; Mean ± SD: 11 ± 7 years; Range: (0.5–27) | Tail length was also significantly longer among exposed females compared to males. No difference noted by smoking status. No difference by duration of exposure (data not provided).
Short-term Exposure
Lin et al. (2013) China; Cross-shift change; Population: 62 plywood workers (17.7% female, mean age 34 year, 17.7% smokers) assessed in 2011.; Outcome: Peripheral blood lymphocytes, change over 8-hr shift; Comet assay, olive tail moment, alkaline conditions (pH = 13), blinded analysis, 50 cells/ subject. | Exposure assessed by air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | Comet assay results before and after work-shift
| Exposure assessed by air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | | | Before exposure (n= 60) | | After exposure (n= 62)
| Exposure assessed by air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | Ln-transformed Tail moment | | 1.47 ± 0.72 | | 2.30 ± 1.28*
| Exposure assessed by air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | * p = < 0.001, paired t-test
| Exposure assessed by air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | Regression coefficients for formaldehyde level, before shift −0.69 (−2.11, 0.73); after shift 3.64 (1.36, 5.92)
Zeller et al. (2011) Germany; Controlled human exposure study; Subjects: 41 healthy volunteers exposed 4 hr/d for 5 d, all male, nonsmokers; Outcome: peripheral lymphocytes. Comet assay: alkaline conditions (pH 13). Analyzed 100 cells/ subject on coded slides. | 12 groups of 2 to 4 persons in a chamber, exposures randomly assigned.; Formaldehyde concentrations: 0 (i.e., background level of 0.01 ppm); 0.3 ppm (0.37 mg/m^3^)^a^ with four peaks of 0.6 ppm (0.74 mg/m^3^); 0.4 ppm (0.49 mg/m^3^) with four peaks of 0.8 ppm (0.98 mg/m^3^); 0.5 ppm (0.67 mg/m^3^); and 0.7 ppm (0.86 mg/m^3^); Peaks were 15 min each,; Four 15-min exercise sessions during exposure. | Results of Comet assay in lymphocytes before and after 4-hr exposure (N = 37)
| | | | Before exposure | | After exposure
| | Tail Moment | | 0.30 ± 0.117 | | 0.33 ± 0.118
| | Tail Intensity | | 2.28 ± 0.492 | | 2.66 ± 0.646*
| | *p = 0.002, Wilcoxon signed rank test, compared to preexposure level.
DNA Adducts
Bono et al. (2010) Italy; (Prevalence study); Population: 20 pathologists from 3 pathology wards who worked in tissue fixation rooms (production rooms) and 20 students and workers from a university’s science labs; Outcome: M_1_dG adducts in DNA extracted from whole blood, methods described in van Helden et al. (2009); compared mean log-transformed M_1_dG adducts by exposure tertile or exposure status, using ANCOVA adjusting for sex, age, smoking | Personal sampling over an 8-hr shift in each subject; LOD 0.05 μg/m^3^; questionnaire data on job-specific work (work in production room where slides were fixed or other areas) & use of personal protection; Mean formaldehyde in production room 0.212 ± 0.047 mg/m^3^, other areas 0.0324 ± 0.0061 mg/m^3^, referents 0.028 ± 0.0025 mg/m^3^ | Mean levels M_1_dG adducts per 10^8^ NNs by exposure group
| | | | N | Mean ± SE | p-Value
| | Referent | | 20 | 2.4 ± 0.3
| | Exposed | | 20 | 5.7 ± 1.3 | 0.045^1^
| | 8-hr TWA
| | <22 μg/m^3^ | | 13 | 2.3 ± 0.44
| | 23–66 μg/m^3^ | | 13 | 2.7 ± 0.55 | 0.775
| | >66 μg/m^3^ | | 13 | 7.3 ± 1.9 | 0.018^2^
| | ^1^ compared to referent.; ^2^ compared to <22 μg/m^3^.
DNA-Protein Crosslinks
Prevalence Studies
Lin et al. (2013) China; (Prevalence); Population: 96 plywood workers exposed to formaldehyde (13.5% female, mean age 33 year, 30.2% smokers) compared to referent group (N=82) (4% female, mean age 31 year, 40% smokers).; Outcome: Peripheral blood lymphocytes: DNA-protein cross-links (DPX), KCl- SDS assay. blinded analysis | Exposure categories by air monitoring and job assignment.; Average concentration:; High exposure, N=38 (making glue): 1.48 mg/m^3^ (range 0.914–2.044); Low exposure, N=58 (sanding boards, pressing wood scraps with glue at high temp): 0.68 mg/m^3^ (range 0.455–0.792); Referent group, N=82 (providing & grinding wood scraps): 0.13 mg/m^3^ (range 0.019–0.252); Exposure duration: 2.52 years | DPX levels in peripheral blood lymphocytes by formaldehyde exposure and years of employment
| | DPX by Formaldehyde Level
| | | | Referent | Low | High
| | DPX (%) | | 22.73 ± 21.47 | 22.53 ± 22.26 | 20.37 ± 20.52
| | *ANOVA p-value = 0.894; trend p-value = 0.682, adjusted for age, gender, smoking status, alcohol use and duration of employment
| | DPX by Number of Work Years
| | | | <1 (N= 57) | 1–3 (N= 64) | >3 (N= 57)
| | DPX (%) | | 19.34 ± 20.77 | 22.10 ± 20.98 | 25.06 ± 20.57
| | ANOVA,^a^ p-value = 0.577;^b^ trend p-value = 0.376.; ^a^adjusted for age, gender, smoking status, alcohol use, formaldehyde exposure levels; ^b^ Calculated using linear regression models with adjustment for age, gender, smoking status, alcohol use and formaldehyde exposure levels.
Shaham et al. (2003) Israel; Prevalence study; Population: 186 workers from 14 hospital pathology departments (mean age 45.8 year, 68.3% female, 36.6% smokers) compared to 213 administrative workers from the same hospitals (mean age 42.1 year, 40.4% female, 44.6% smokers). Age distribution, gender, origin (ethnicity), and years of education differed significantly between the groups but were adjusted for in the analysis.; Outcome: peripheral blood lymphocytes. Mean percent DPX of total DNA in quantity white blood cells, K-SDS method, double blinded. | Field and personal air sampling, sample duration 15 min, multiple times during work-day (# not reported).; Concentration; Low exposure: 0.49 (range 0.049–0.86) mg/m^3^; High exposure: 2.8 (range 0.89–6.9) mg/m^3^; Duration:; Mean: 15.9 years; Range: 1–51 years | Comparison of DNA-protein crosslinks by exposure
| | | | Referent | | Exposed
| | Mean DPX/total DNA ± SE | | 0.14 ± 0.006 | | 0.21 ± 0.006**
| | **p <0.01, adjusted for age, gender, smoking, education and region of origin.
| | Mean frequency DNA-protein crosslinks by level of exposure
| | | | Referent | Low | High
| | Mean DPX/ total DNA^1^ | | 0.14 | 0.19 | 0.20
| | ^1^SE was not provided. Trend by exposure level was not statistically significant.
Shaham et al. (1997) Israel; Prevalence study; Population: 12 pathology workers (mean age 44 year) compared to 8 age-matched controls (mean age 41 year).; Outcome: Mean percent DPX, K-SDS method, double blinded; Related references: Shaham et al. (1996) | Field and personal air sampling, sample duration 15 min, multiple times during work-day (# not reported).; Concentration:; Mean: NR; Range: 3.4–3.8 mg/m^3^; Exposure duration mean 13 years (range 2–31 years) | Frequency of DPX by Exposure
| | | | Unexposed | | Exposed
| | Mean DPX % | | 23 ± 7 | | 29 ± 6*
| | *p = 0.03, ANOVA adjusting for smoking status.
| | Years of exposure linearly correlated with DPX levels.
Short-term Studies
Lin et al. (2013) China; Cross-shift change; Population: 62 plywood workers (17.7% female, mean age 34 year, 17.7% smokers) assessed in 2011.; Outcome: Blood lymphocytes: % cross links measured before and after 8-hr shift, blinded analysis. | Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | DPX frequency before and after work-shift
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | | | Before exposure (n=62) | | After exposure (n= 60)
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | DPX (%) | | 27.22 ± 10.07 | | 31.68 ± 14.19*
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | * p = 0.019, paired t-test.
| Air sampling and job function.; Mean exposure: 0.27 ± 0.20 mg/m^3^; Range: 0.012–0.67 mg/m^3^ | Regression coefficients for formaldehyde level, before shift 1.70 (−17.84, 21.24); after shift −6.04 (−31.23, 19.15).
DNA Repair
Schlink et al. (1999) Germany; Population: Anatomy students, Group 1, 41 students from one university course, 3-hr labs, 2 times per wk (43.9% female, ages 21-30 year, 39% smokers); Group 2, 16 students from a different university course (50% female, ages 21–27 year, 37.5% smokers), and Referent, 10 unexposed students (60% female, ages 22–44 year, 30% smokers); no previous formaldehyde exposure; Outcome: O^6^-alkylguanine DNA alkyl-transferase activity in peripheral blood lymphocytes (modification of Klein and Oesch (1990), expressed as fmol MGMT/ 10^6^ cells (LOD 1 fmol MGMT/ 10^6^ cells), blind to period of sample (before or after); Blood samples collected before 1^st^ class and after days 50 and 111 | Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | MGMT activity change compared (U-test, paired data) before and after exposure; as well as between exposure groups (Wilcoxon, Mann and Whitney U-test)
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | Mean MGMT activity by exposure group (fmol MGMT/ 10^6^ cells)
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | | N | Day 0 | Day 50 | Day > 90
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | Group 1 | 41 | 133.2 | 131.1^1^ | 128.2^1^
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | Group 2 | 16 | | | 146.9^2^
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | Referent | 10 | 138.9
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | ^1^p >0.05 compared to Day 0.; ^2^p >0.05 compared to referent.
| Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | MGMT activity did not differ by gender, smoking, allergy status, or alcohol consumption.
Hayes et al. (1997) USA; Panel study; Population: 29 students (with adequate samples) exposed to formaldehyde for 9 wks during embalming course 16 male, 7 females, 6 smokers. Mean duration of embalming 125 min. 15 with previous embalming exposure within previous 90 da; Outcome: O^6^-alkylguanine DNA alkyltransferase activity in peripheral lymphocytes, expressed as pmol AGT/ mg protein (LOD 0.006 pmol AGT/ mg protein), blind to period of sample (before or after); blood samples collected in morning before 1^st^ class and after 9 wks; Related reference: Suruda et al. (1993) | Personal sampling for 121 of 144 embalmings; Exposure concentration:; Mean: 1.72 mg/m^3^; Range: (0.18–5.29) mg/m^3^; Duration:; 9 wks (0.173 years); Total number of reported embalmings correlated with estimated cumulative formaldehyde exposure (r = 0.59, p < 0.01). | Individual data pre- and postcourse AGT activity in peripheral blood lymphocytes depicted in graphs by embalming experience during previous 90 d (yes/ no), decreased in 17 students, increased in 6 students (ANOVA adjusting for age, sex and smoking, p < 0.05).
P53 protein levels in blood
Attia et al. (2014) Egypt; Prevalence study; Population: 40 employees at cosmetic manufacturing company (23% male, mean age 25.8 years, 20% smokers) randomly selected, compared to referent (N=20) selected from hospital administrative department with comparable SES & no history of occupational exposure to formaldehyde (35% male, mean age 34 years, 15% smokers); Outcome: Peripheral blood; plasma MDA (commercial kit), plasma p53 (p53 enzyme-linked immunosorbent assay kit). Blinding not stated. Statistical analyses of coded data (blinded assumed). Exposed compared to referent, means (Student’s t-test), correlation between urinary formate and MDA or p53 using linear regression | Urine formic acid according to Hopner & Knappe, 1974; unclear how to relate urine formic acid levels to air concentrations; Urinary formate; Exposed: 53.4 ± 15.01 mg/L; Referent: 12.7 ± 4.57 mg/L; P <0.05 | Comparison of plasma p53 and plasma MDA concentrations in exposed and referent groups
| | | | Referent | Exposed | p-Value
| | Plasma p53 (U/mL) | | 2.78 ± 0.48 | 13.34 ± 4.67 | <0.05
| | Plasma MDA (nmol/ml) | | 3.59 ± 0.83 | 9.73 ± 2.72 | <0.05
| | Correlations in exposed group:; Urinary formate & p53, r=0.91 p <0.001; Urinary formate & MDA, r =0.79, p <0.001; Plasma MDA & plasma p53, r =0.81, p <0.001
| | Age and gender were not associated with plasma p53, plasma MDA or urinary formate.
Shaham et al. (2003) Israel; Prevalence study; Population: 186 workers from 14 hospital pathology departments (mean age 42.1 year, 59.6% male, 36.6% smokers) compared to 213 administrative workers from the same hospitals (mean age 45.8 year, 31.7% male, 44.6% smokers). Age distribution, gender, origin (ethnicity), and years of education differed significantly between the groups but were adjusted for in the analysis.; Outcome: p53 proteins (wild type and mutant) in serum, p53 quantitative ELISA kit immunoassay, mutant p53 in serum using quantitative ELISA kit immunoassay. Categorical analysis of p53 levels (>pg/mL), exposure groups compared using chi-square test; logistic regression of p53 >150 pg/mL | Field and personal air sampling, sample duration 15 min, multiple times during work-day (# not reported).; Concentration; Low exposure: 0.49 (range 0.049–0.86) mg/m^3^; High exposure: 2.8 (range 0.89–6.9) mg/m^3^; Duration:; Mean: 15.9 years; Range: (1–51) years | Comparisons of exposure, serum total p53, serum mutant p53 and DPXs (OR, 95% CI)
| | | | Total | Male | Female
| | Total p53 protein > 150 pg/mL^a^
| | Referent | | 1.0 | 1.0 | 1.0
| | Exposed | | 1.6 (0.8–3.1) | 2.0 (0.9–4.4) | 0.8 (0.2–2.7)
| | Total p53 protein > 150 pg/mL^b^
| | DPX ≤ 0.187^b^ | | 1.0 | 1.0 | 1.0
| | DPX > 0.187 | | 2.5 (1.2–5.4) | 1.9 (0.5–7.2) | 2.8 (1.1–7.1)
| | ^a^Logistic regression models adjusted for sex, age and smoking.; ^b^In the exposed group, logistic regression models adjusted for sex, age and smoking.; ^b^DPX expressed as % of total DNA.
| | Correlations:; Total p53 protein and mutant p53 protein, r =0.75, p <0.01
| | Proportion p53 > 150 pg/mL among exposed
| | DPX ≤ 0.187 | | | 33.3%
| | DPX > 0.187 | | | 55.7% (p <0.01)
Genetic Susceptibility
Costa et al. (2015); Costa et al. (2019) Portugal; Prevalence study; Population: 84 anatomy pathology workers from 9 hospital laboratories, exposed to formaldehyde for at least 1 year, compared to 87 non-exposed employees from administrative offices in same geographic area. Exclusions: cancer history, radiation therapy or chemotherapy, surgery with anesthesia or blood transfusion in last year. Exposed and referent similar for mean age 39 years, 77% females, 25% smokers. Outcome: Peripheral blood samples, coded, analyses blinded to exposure status.; Differences in genotype distribution evaluated using Pearson’s chi-square test, effect modification by genotype in regression models of exposure on ln % tDNA (comet assay) and chromosome aberrations, CYP2E1 rs6413432, GSTM1 deletion, GSTT1 deletion, GSTP1 rs1695, XRCC1 rs1799782, XRCC1 rs25487, PARP1 rs1136410, MUTYH rs3219489, XRCC3 rs861539 | Exposure assessed via air sampling and deriving an 8-hr TWA for each subject.; Exposure concentration:; Mean: 0.38 ppm (0.47 mg/m^3^); Range: 0.28–0.85 ppm (0.34–1.05 mg/m^3^); Exposure duration 12.0 ± 8.2 years | Effect modification by genetic polymorphisms on associations of formaldehyde with markers of genotoxicity (mean ratio, 95% CI)
| | | Referent | | Exposed
| | | N | MR (95% CI) | N | MR (95% CI)
| | CYP2E1 rs6413432 (% tDNA)
| | T/T | 53 | 1.00 | 51 | 1.61 (1.20–2.16)
| | T/A + A/A | 15 | 0.84 (0.54–1.30) | 7 | 0.42 (0.20–0.89)
| | GSTP1 rs1695 (CSAs)
| | Ile/Ile | 32 | 1.00 | 37 | 5.43 (2.04–14.46)
| | Ile/Val + Val/Val | 55 | 1.79 (1.14–7.94) | 47 | 0.26 (0.97–3.27)
| | XRCC1 rs1799782 (% tDNA)
| | Arg/Arg | 67 | 1.00 | 53 | 1.46 (1.10-1.93)
| | Arg/Trp | 2 | 0.19 (0.06–0.57) | 6 | 4.93 (1.33–18.32)
| | PARP1 rs1136410 (Multiabberrant cells)
| | Val/Val | 60 | 1.00 | 50 | 5.97 (2.34–15.25)
| | Val/Ala | 8 | 3.00 (0.55–16.4) | 9 | 0.09 (0.01–0.95)
| | Regression models adjusted for age, gender, smoking habit, and fruit consumption.
| | Micronuclei frequency (%/1,000 cells) by genetic polymorphisms in formaldehyde exposed and unexposed workers
| | Gene site | Controls | | Exposed
| | Gene site | N | Mean ± SE | N | Mean (SE)
| | CYP2E1 rs6413432
| | BNbud
| | T/T | 53 | 0.36 ± 0.077 | 51 | 0.80 ± 0.12
| | T/A + A/A | 15 | 0.20 ± 0.11 | 7 | 1.57 ± 0.20^*^
| | GSTP1 rs1695
| | MNB
| | Ile/Ile | 28 | 0.14 ± 0.07 | 29 | 0.45 ± 0.11
| | Ile/Val + Val/Val | 41 | 0.20 ± 0.07 | 33 | 0.82 ± 0.15^*^
| | FANCA rs7190823
| | MNL
| | Thr/Thr | 9 | 2.33 ± 0.93 | 12 | 2.33 ± 0.57
| | Thr/Ala + Ala/Ala | 77 | 2.84 ± 0.32 | 70 | 4.74 ± 0.44^*^
| | ^*^ p-values CYP2E1 rs6413432 A variant, 0.022; GSTP1 rs1695 Val variant 0.05; FANCA rs7190823 Ala variant 0.019
Ladeira et al. (2013) Portugal; Prevalence study; Population: 54 hospital workers in histopathology labs compared to 82 administrative staff.; Outcome: Genotyping XRCC3 Met241Thr, ADH5 Val309Ile, ADH5 Asp353Glu; associations of polymorphism with mean micronuclei, nucleoplasmic bridges and nuclear buds in lymphocytes and buccal cells within exposed and referent groups, Kruskal-Wallis test; Related references: Ladeira et al. (2011) | Personal air sampling, 6-8 hours, estimated 8-hr TWA; Exposure conc.:; Mean TWA 8 hr 0.2 ± 0.14 mg/m^3^; Mean ceiling value: 1.4 ± 0.91 mg/m^3^, range 0.22–3.6 mg/m^3^; Exposure duration: 14.5 (1–33) years | Frequency of micronuclei and nuclear buds (mean ± SE) in lymphocytes by exposure and genotype (number in parentheses)
| | Endpoint | | Genotypes
| | MN
| | | | XRCC3
| | | | Met/Met | Thr/Met | Thr/Thr
| | Exposed (p=0.37) | | 2.92 ± 0.93 (13) | 5.05 ± 0.98 (22) | 3.53 ± 0.80 (19)
| | Referent (p=0.62) | | 1.15 ± 0.46 (20) | 0.70 ±0.30 (27) | 0.74 ± 0.23 (35)
| | | | ADH5
| | | | Val/Val | Val/Ile
| | Exposed (p=0.02) | | 2.57 ± 0.65 (21) | 4.91 ± 0.75 (33)
| | Referent (p=0.17) | | 0.97 ± 0.28 (29) | 0.75 ± 0.23 (53)
| | | | ADH5
| | | | Asp/Asp | Asp/Glu
| | Exposed (p=0.70) | | 4.08 ± 0.91 (24) | 3.93 ± 0.67 (30)
| | Referent (p=0.21) | | 0.86 ± 0.23 (35) | 0.81 ± 0.26 (47)
| | NBUD
| | | | XRCC3
| | | | Met/Met | Thr/Met | Thr/Thr
| | Exposed (p=0.00) | | 0.38 ± 0.18 (13) | 1.5 ± 0.33 (22) | 0.21 ± 0.12 (19)
| | Referent (p=0.04) | | 0.2 ± 0.09 (20) | 0.04 ± 0.04 (27) | 0.03 ± 0.29 (35)
| | | | ADH5
| | | | Val/Val | Val/Ile
| | Exposed (p=0.27) | | 0.62 ± 0.28 (21) | 0.88 ± 0.21 (33)
| | Referent (p=0.06) | | 0.00 ± 0.0 (29) | 0.11 ± 0.04 (53)
| | | | ADH5
| | | | Asp/Asp | Asp/Glu
| | Exposed (p=0.74) | | 0.71 ± 0.23 (24) | 0.83 ± 0.25 (30)
| | Referent (p=0.63) | | 0.06 ± 0.04 (35) | 0.09 ± 0.04 (47)
| | No differences noted for nucleoplasmic bridges or micronuclei in buccal cells (data provided in article)
Santovito et al. (2011) Italy; Prevalence study; Population: 20 pathology workers (mean age 45.7 year) compared to 16 workers from the same hospital (mean age 42.1 year); similar age and gender distribution. All subjects were non-smokers and had not consumed alcohol in 1 year.; Outcome: Genotypes GSTT, GSTM; associations of polymorphisms with CA per cell and % of cells with aberrations within exposed and referent groups; generalized linear models with Poisson distribution errors adjusted for gender and age | Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | Frequency of chromosomal aberrations per cell (mean ± SE) in lymphocytes by exposure and genotype (number in parentheses)
| Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | | | Exposed | | Referent
| Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | GSTT-pos | | 0.028 ± 0.003 (16) | | 0.01 ± 0.004 (12)
| Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | GSTT-null | | 0.04 ± 0.015 (4) | | 0.013 ±0.009 (4)
| Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | GSTM-pos | | 0.031 ± 0.004 (17) | | 0.01 ± 0.004 (10)
| Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | GSTM-null | | 0.023 ± 0.003 (3) | | 0.012 ± 0.008 (6)
| Exposure conc:; Personal air sampling, 8-hr duration.; Referent: Mean: 0.036 ± 0.002 mg/m^3^; Pathologists: Mean: 0.073 ± 0.013 mg/m^3^; Exposure duration:; Mean: 13 years; Range: 2–27 years | No differences also were found for the % of cells with chromosomal aberrations (data provided in article).
Jiang et al. (2010) China; Prevalence; Population: 151 male workers from 2 plywood plants (mean age 27.4 year, 52.3% smokers) compared to 112 unexposed workers at a machine manufacturer in same town (mean age 28.7 year, 42.9% smokers).; Outcome: genotypes GSTM1, GSTT1, GSTP1; associations with olive TM and CBMN frequency within exposed and referent; ANCOVA adjusted for age, smoking and alcohol | Exposure assessed by job title and personal air monitoring.; Exposure concentration ppm converted to mg/m^3^ by EPA.; 1.08 mg/m^3^, range 0.1–7.75 mg/m^3^; Duration:; Mean 2.51 years; Range: (0.5–25) years | Frequency of olive TM (geometric mean (95% CI) in lymphocytes by exposure and genotype (number in parentheses)
| | | | Exposed | | Referent
| | GSTM1-pos | | 3.27 (2.83–3.78) 74) | | 1.01 (0.77–1.32) (46)
| | GSTM1-null | | 3.86 (3.31–4.5) (77) | | 0.87 (0.69–1.1) (66)
| | | | P =0.07 | | P =0.43
| | GSTT1-pos | | 3.72 (3.26–4.25) (83) | | 1.04 (0.82–1.31) (63)
| | GSTT1-null | | 3.36 (2.83–3.99) (68) | | 0.8 (0.61–1.04) 49)
| | | | P =0.47 | | P =0.11
| | GSTP1-Ile/Ile | | 3.64 (3.19–4.16) (90) | | 0.96 (0.74–1.23) (58)
| | GSTP1 Val pos | | 3.43 (2.87–4.1) (61) | | 0.89 (0.7–1.14) (54)
| | | | P = 0.49 | | P = 0.83
| | Frequency of ln CBMN (mean ± SD) in lymphocytes by exposure and genotype (number in parentheses)
| | | | Exposed | | Referent
| | GSTM1-pos | | 5.57 ± 3.45 (74) | | 2.91 ± 1.5 (46)
| | GSTM1-null | | 5.5 ± 3.32 (77) | | 2.5 ± 1.15 (66)
| | | | P = 0.84 | | P = 0.18
| | GSTT1-pos | | 5.59 ± 3.51 (83) | | 2.75 ± 1.41 (63)
| | GSTT1-null | | 5.46 ± 3.22 (68) | | 2.57 ± 1.19 (49)
| | | | P = 0.70 | | P = 0.47
| | GSTP1-Ile/Ile | | 5.01 ± 2.98 (90) | | 2.79 ± 1.36 (58)
| | GSTP1 Val pos | | 6.32 ± 3.78 (61) | | 2.54 ± 1.27 (54)
| | | | P = 0.05 | | P =0.26

ADH, alcohol dehydrogenase; AGT, O^6^-alkylguanine-DNA alkyltransferase; ANOVA, analysis of variance; C –, centromere negative; C+, centromere positive; CA, chromosomal aberration; CB-MN or CBMN, cytokinesis block-micronucleus; CFU-GM, colony forming unit-granulocyte/macrophage; CI, class interval; CSA, chromosome-type aberration; CSG, centromere separation general; CTA, chromatid-type aberration; DAPI, diamidinophenylindole; DPX, DNA-protein crosslink; EA, ethyl acetate; ELISA, enzyme-linked immunosorbent assay; FISH, fluorescence in situ hybridization; GST, glutathione S-transferase; HCHO, formaldehyde; HF, high frequency; IRR, incidence rate ratio; K-SDS/KCl-SDS, potassium chloride-sodium dodecyl sulfate; LOD, level of detection; LTR, lymphocyte transformation rate; M_1_dG, malondialdehyde-deoxyguanosine; MAK, maximum permissible concentration (German); MDA, malondialdehyde; MGMT, O^6^-methylguanine methyl transferase; MN, micronucleus; MR, mean ratio; NSM, number of scored metaphases; OR, odds ratio; PARP, poly (ADP-ribose) polymerase; PCD, premature centrosome division; PI, proliferation index; SCE, sister chromatid exchange; SD, standard deviation; SE, standard error; SEM, standard error of the mean; tDNA, tail DNA; TWA, total weighted average; XRCC, X-ray repair cross complementing.

### C.3.7 Summary Table by Genotoxicity Endpoint

A text summary of the available genotoxicity data that emphasizes genotoxicity studies incorporating inhalation formaldehyde exposure and related experiments (i.e., given the known toxicokinetics of inhaled formaldehyde) is provided in Section 3.2.5 (Evidence on Mode of Action) in the Toxicological Review. Table C-21 below provides a summary of the most relevant data organized by genotoxicity endpoint, as compared to the organization by test system in the previous sections. In addition, when possible, this table separates the summary into investigations of respiratory- versus nonrespiratory-related tissues or systems. Thus, observations of genotoxicity in the upper respiratory tract (URT) and in peripheral blood lymphocytes (PBLs) following inhalation exposure or in related in vitro systems are presented in Table C-21 in order of their importance and relevance to cancer risk beginning with gene mutations, DPXs and DDCs, DNA adducts, CAs, MN, DNA strand breaks, SCE, and other effects. Overall, the evidence supports the conclusion that formaldehyde is genotoxic. Particular weight is placed on the following observations:

1) Consistent observations of mutations in exposed rodents and various in vitro systems;
2) Observations of CAs, MNs, and SSBs in exposed humans across a range of studies, occupations, and exposure scenarios, with supporting, similar findings in exposed rodents and in vitro systems; and
3) Consistent observations of DPX detected in multiple experimental systems, showing a concentration-dependent increase, and concordance of DPX distribution with sites of tumors in the nose.

Table C-21 Genotoxicity summary table

Genotoxicity endpoint(s) | Experimental system | Genotoxicity evidence (in descending relevance) | Other relevant information or limitations | Endpoint summaries | Endpoint conclusion
Gene Mutations | Respiratory tract tissues or in vitro systems | +(1/2) In vivo, rodent (inhalation); + 1/1 chronic; 0/1 subchronic studies; + (5/5) In vitro, human cell lines, acute studies; +(8/10) In vitro, rodent cell lines, acute studies; +(13/17) Nonmammalian systems | In vivo rodent studies analyzed SCCs from a chronic study and non-neoplastic nasal mucosa from a subchronic study at 18.45 mg/m^3^; All in vitro studies assume MeOH coexposure; cellular sources both POE and systemic sites; Negative in vitro rodent data for HPRT; + results include colony formation and mutation frequency | Mutations induced by formaldehyde across a range of in vitro systems. Mutations observed in SSC in nasal tissues of exposed rodents at 18.45 mg/m^3^ in one chronic inhalation study. | Observation of gene mutations in nasal SSC in one chronic-duration rodent study (which only tested high formaldehyde levels), with confirmatory evidence from in vitro test systems across several species. No mutations in subchronic-duration rodent study. No studies of exposed humans or primates.
Gene Mutations | Other tissues | +(1/2) in vivo, rodent (inhalation); dominant lethal studies; +(1/2) in vivo, rodent (i.p.); dominant lethal mutation studies | Formalin inhalation exposure at 200 mg/m^3^ prevents interpretation; another inhalation study at 1.5 mg/m^3^ was equivocal; i.p. exposure with MeOH co-exposure caused + DLM in rats (0.125 mg/kg), but not in mice (20 mg/kg) at much higher levels | Results are interpreted as equivocal; the available studies do not provide evidence of mutations in other tissues
Chromosomal aberrations (CA) | Respiratory tract tissues or in vitro systems | +(1/1) in vivo, rodent (inhalation): short term study; +(4/4) In vitro, human cells/cell lines, acute studies; +(5/6) In vitro, rodent cell lines, acute studies | In vivo rat study at 18.45 mg/m^3^ with 4-wk exposure; In vitro studies assume co-exposure to MeOH; cell sources both POE and systemic sites; 1 equivocal CA study in a rodent cell line | CAs were observed in the only in vivo rodent study, which is supported by positive results in human and rodent cells in vitro. | Evidence from exposed humans across several different occupations is consistent with the induction of CAs. These results are supported by observations of CAs in the only available in vivo rodent study (4 wks at high levels), which was consistent with findings from multiple in vitro studies of human and rodent cells lines
Chromosomal aberrations (CA) | Other tissues | +(11/16) in vivo, human (inhalation): PBLs; +(1/5) in vivo, rodent (inhalation): short term studies; +(2/2) in vivo, rodent (gavage, p.o.): acute studies; +(1/4) in vivo, rodent (i.p.): acute or short term studies | In humans, half + CAs were observed in pathologists and half among industrial workers; often, these studies involved relatively higher formaldehyde exposure levels (e.g., average >0.2 mg/m^3^) and longer employment duration (e.g., average >10 year); The only positive rodent inhalation study involved MeOH co-exposure*; 4 studies used PFA; Oral exposure in rats and mice involved MeOH co-exposure, although 1 study indicated it takes >10× MeOH to cause a similar level of CAs; The + i.p. study was in rat bone marrow cells after 4-wk exposure; − studies were acute, mice studies | Most of the human studies interpreted with higher confidence observed increased CA in PBLs; Lower exposure levels may explain null findings.; Rodent results are interpreted as equivocal. The rodent studies do not provide evidence that CAs are induced in other tissues; however, the data suggest the possibility that rats might be more sensitive and that exposure duration is important.
Micronuclei (MN) | Respiratory tract tissues or in vitro systems | +(11/13) in vivo, human (inhalation); +(0/1) in vivo, rodent (inhalation); short term study; +(5/5) In vitro, human cell line; acute study; +(4/4) in vitro, rodent cell lines; acute studies; +(1/3) nonmammalian studies | MN reported in buccal and nasal cells, occupational (average >0.5 mg/m^3^), anatomy or embalming courses (average >0.5 mg/m^3^ with intermittent peaks). No increase after 5–10 d in 2 controlled human exposure studies, In vivo rat study at 18.45 mg/m^3^ for 4 wk (in BAL); MN observed in primary human blood cultures, and in 3 in vitro rodent studies with no MeOH co-exposure; remaining cell studies assume MeOH; cellular sources both POE and systemic sites | Consistently increased frequency of MN or related endpoint in buccal and/ or nasal cells of exposed individuals; Consistent evidence of MN across a range of in vitro mammalian cells, but not in a short term rodent inhalation study. | Available evidence suggests increased MN levels associated with cumulative exposure; the pattern of chromosomal loss (monocentromeric and multi-centromeric micronuclei) was consistent with aneuploidy in exposed individuals
Micronuclei (MN) | Other tissues | +(11/16) in vivo, human (inhalation) PBLs, +(1/2) in vivo, rodent (inhalation); short-term studies; +(1/5) in vivo, rodent (i.p., i.v., p.o. or gavage); acute studies | MN reported in PBLs of workers from plywood and formaldehyde production industry, and pathology, anatomy, and mortuary lab students, at exposure concentrations of 0.1–0.5 mg /m^3^. Null results in studies with low sensitivity. No increase after 5 days in controlled human exposure study. Prevalence increases with longer exposure duration.; In rodents, MN were in bone marrow erythrocytes at 12.8 mg/m^3^ with 10-wk exposure, but not in peripheral blood at 18.45 mg/m^3^ with 4-wk exposure. The + non-inhalation study was an oral rat study of gastric epithelial cells; all − studies were in mice | Most of a large set of studies that measured MN in PBLs reported increased levels among exposed participants working in diverse exposure settings and in several countries.; The two rodent inhalation studies suggest the possibility that MN induction may require longer exposure duration, but results were mixed; data suggest the possibility that rats might be more sensitive.
Aneuploidy | Respiratory tract tissues or in vitro systems | +(1/3) In vitro, human cell lines; short-term studies; +(1/3) in vitro, rodent cell lines; short-term studies | All negative in vitro studies have coexposure with MeOH | Inconsistent results from in vitro human or rodent cell lines; Methanol co-exposure is likely to influence the aneuploidy in cultured cells | Chromosome aneuploidies are consistent with study findings of CA and monocentromeric and multicentromeric micronuclei in PBLs of exposed humans
Aneuploidy | Other tissues | +(3/4) in vivo, human (inhalation); +(1/3) in vitro, rodent cell lines; +(1/3) in vitro, human cell lines | An occupational study in humans reported monosomy 7 and trisomy 8 in cultured CFU-GM colony cells from peripheral blood. Analysis of same cohort with bigger sample size detected aneuploidy in several chromosomes. Two in vitro studies each from rodent and human cell lines used MeOH-free HCHO, one positive study in human cells has co-exposure with MeOH. | Significant increase in chromosome aneuploidy in cultured CFU-GM colony cells among subset of highly exposed workers compared to matched controls | Chromosome aneuploidies are consistent with study findings of CA and monocentromeric and multicentromeric micronuclei in PBLs of exposed humans
DNA adducts | Respiratory tissues or in vitro systems* | +(2/2) in monkeys (inhalation) hm-DNA adducts; +(3/4) in rats (inhalation) hm-DNA adducts; +(2/2) in vitro human cell lines, hm-DNA adducts; +(1/1) in vitro rodent cell lines, hm-DNA adducts; +(10/10) in cell-free systems, hm-DNA adducts | No in vivo studies in humans showing hm-DNA adducts with a direct exposure to formaldehyde.; Detectable hm-DNA adducts in all nasal passages, but not in lungs of rats.; High endogenous hm-DNA adduct levels rats and monkeys, but monkeys > rats | All tissues in nasal passages demonstrated hm-DNA adducts except lung tissue of rodents.; Endogenous levels of hm-DNA adducts are very high in both rats and monkeys compared to exogenous hmDNA adducts.; Monkeys have much higher endogenous hm-DNA adduct levels compared to rats. | Formaldehyde readily forms hm-DNA adducts in tissues at POE. However, available evidence does not show their formation in distal tissues.
DNA adducts | Other tissues | +(1/1) in vivo, human, M1G adduct; +(0/2) in vivo, monkeys (inhalation), acute studies; +(0/2) in vivo, rodent (inhalation), acute studies | One study reported M1G adducts in peripheral blood of pathologists, uncertainties with regard to site of DNA interactions. hm-DNA adducts were not found in distal tissues of exposed monkeys or rodents | Absence of hm-DNA adducts in distal tissues suggest lack of formaldehyde transport to distal sites.; Limited evidence of formaldehyde-induced oxidative DNA damage. | Formaldehyde readily forms hm-DNA adducts in tissues at POE. However, available evidence does not show their formation in distal tissues.
DDC | Respiratory tissues or in vitro systems* | +(1/1) in vivo, rat (inhalation), acute study; +(3/3) in vitro, cell-free systems | Only one in vivo study reports DDC. But DDC are unstable and could be generated as an artifact. | Limited evidence of DDC formation by formaldehyde in vivo. | Limited evidence that formaldehyde inhalation results in DDC although artifacts were not ruled out.
DDC | Other tissues | +(0/1) in vivo monkey (inhalation) short-term study; +(0/1) in vivo rat (inhalation) short-term study | DDC were not detectable in distal tissues. | DDC have not been detected in distal tissues | Limited evidence that formaldehyde inhalation results in DDC although artifacts were not ruled out.
DNA-Protein Crosslinks | Respiratory tissues or in vitro systems* | +(1/1) in vivo, monkeys (inhalation), acute study; +(7/11) in vivo, rodents (inhalation), acute studies; +(30/30), in vitro, human cell lines, acute studies; +(21/21) in vitro, rodent cell lines, acute studies; +(3/3) nonmammalian systems; +(4/4) cell-free systems | Concentration-dependent increase in DPX in rodents (0.37–12.1 mg/m^3^) and monkeys (0.86–7.37 mg/m^3^); DPX demonstrated in nasal mucosa of rats but absent from olfactory mucosa and lung; a negative study in BAL cells used formalin vapors | Consistent evidence of DPX across multiple test systems (two species in vivo, different cell lines, nonmammalian and cell-free test systems) | Anatomical distribution of DPX in rats corresponds to sites of tumor incidence, cell proliferation, and cytotoxicity in the nose. However, no mechanism is identified for DPX formation in PBLs of occupationally exposed individuals.
DNA-Protein Crosslinks | Other tissues | +(2/3) in vivo, human (inhalation) PBLs; +(4/8) in vivo, rodent (inhalation) | Occupational settings, one null study of plywood workers had low sensitivity (referent group had high exposure), no difference in prevalence by exposure group, but increase in DPX was observed over 8-hr shift. Positive rodent studies have coexposure with MeOH. | In vivo human studies show exposure duration-dependent increase in DPX in PBLs, but animal in vivo studies are confounded by MeOH coexposure.
DNA strand breaks | Respiratory tissues or in vitro systems* | +(1/1) in vivo, rodent (inhalation), short-term study; +(10/12) in vitro, human cells, acute studies; +(3/7), in vitro, rodent cells/cell lines, acute studies; +(4/4) nonmammalian systems | Only one in vivo study and several cell culture studies reports SSB formation, but most of these studies have coexposure with MeOH.; Human cells were more sensitive to SSB formation by HCHO exposure (0.005–0.8 mM); Excision-repair deficient yeasts were more sensitive compared to repairproficient strains. | Single strand breaks in rat study were positively associated with concentration. | Some evidence for SSB with dose-response in respiratory tissues from an inhalation study in rats, and consistent evidence in PBLs from several studies of human exposure and from rodent studies
DNA strand breaks | Other tissues | +(8/9) in vivo, human (inhalation) PBLs, +(3/4) in vivo, rodent (inhalation), short-term studies | Exposure settings were occupational with means > 0.2 mg/m^3^, 1 controlled human exposure study (4-hr duration). Categorical analysis by one study showed exposure-response trend beginning at 2nd quintile (mean 0.14 mg/m^3^) Positive rodent in vivo studies have co-exposure with MeOH. | Consistent evidence of SSB formation in both human and rodent in vivo studies | Some evidence for SSB with dose-response in respiratory tissues from an inhalation study in rats, and consistent evidence in PBLs from several studies of human exposure and from rodent studies
Sister chromatid exchange (SCE) | Respiratory tissues or in vitro systems* | +(6/6) in vitro, human cells/cell lines, short-term studies; +(13/14) in vitro hamster cell lines, short-term studies | Positive studies included mostly co- exposure with MeOH, but several studies in both human and animal cell lines, which used methanol-free formaldehyde, were also positive. | Consistent evidence of SCE formation from in vitro human and rodent cell lines | No in vivo studies in animals, and less consistent results in exposed humans
Sister chromatid exchange (SCE) | Other tissues | +(8/16) in vivo human (inhalation) PBLs; +(0/3) in vivo, rat (inhalation) short-term studies | Several studies of occupational exposure showed increased SCE levels.; Although MeOH-free or MeOH-coexposed rat studies were negative, male rats received MeOH-free formaldehyde were positive in bone marrow cells. | Evidence that SCE is induced in some exposed human populations, although the results across studies are not consistent | No in vivo studies in animals, and less consistent results in exposed humans
Other effects (cell transformation; DNA repair inhibition; unscheduled DNA synthesis; gene conversion, crossing over and translocation) | Respiratory tissues or in vitro systems* | +(4/7) in vitro, human primary cells/cell lines, (2/5 UDS) and (2/2 DNA repair inhibition, short-term studies; +(4/5) in vitro, rodent cell lines, short-term studies (1/1 UDS; 3/4 cell transformation); +(8/8) nonmammalian system; [(1/1) DNA repair inhibition; +(2/2) gene conversion; +(3/3) genetic crossing over/recombination; +(2/2) heritable translocation] | Although most of the in vitro and nonmammalian studies were positive for other genotoxic effects, these studies had co-exposure with MeOH. | Available evidence suggests a variety of other genotoxic endpoints induced by formaldehyde exposure, which may play a supplemental role in overall genotoxicity. | Many of the other genotoxic endpoints support the overall genotoxicity and mutagenicity of formaldehyde across multiple experimental systems.
Other effects (cell transformation; DNA repair inhibition; unscheduled DNA synthesis; gene conversion, crossing over and translocation) | Other tissues | +(1/2) in vivo human (inhalation) | Change in O6-alkylguanine DNA alkyltransferase activity in PBLs before and after 2- to 3-month exposure in embalming or anatomy labs | Evidence is inadequate to conclude effect on DNA repair inhibition | Many of the other genotoxic endpoints support the overall genotoxicity and mutagenicity of formaldehyde across multiple experimental systems.

## C.4 SENSORY IRRITATION (SUPPORTING INFORMATION FOR HAZARD)

Information supporting the evidence synthesis on sensory irritation in Section 3.2.1 of the Toxicological Review is presented in Tables C-22 (human laboratory exposure studies) and C-23 (human occupational studies) below.

Table C-22 Summary of epidemiology studies of laboratory exposures to formaldehyde and human sensory irritation

Reference, study design, exposure levels, confidence | Results
Kriebel et al. (1993) (Massachusetts); Panel study, 24 clinical anatomy students dissecting cadavers during 10-wk lab once a wk, 3 hrs. Outcome: Symptoms recorded before, during and after the lab; ATS questionnaire for baseline and modified brief questionnaire during lab, references provided.; Exposure: Personal samples in breathing zone (1- to 1.5-hr duration).; Geometric mean 0.73 ppm (SD 1.22 ppm). Range 0.49–0.93 ppm (n=8). No trend in concentrations over semester. Formaldehyde levels in three air samples in the cavities of the cadavers were 3.0, 3.6 and 4.3 ppm.; Analysis: Multivariate linear regression models; mean prelab and cross-lab change in symptoms analyzed using random effects models.; High confidence | Average symptom prevalence increased from beginning to end of weekly lab session by 43%.; Prevalence (%) Before, Midway and After Lab Session
| Symptom | pre | mid- | Post
| Eyes | 16 | 66 | 59
| Nose | 46 | 75 | 67
| Throat | 25 | 45 | 40
| Breathing | 16 | 41 | 36
| Cough | 15 | 26 | 20
| Analysis indicated that magnitude of increase in symptom prevalence across lab session decreased as semester advanced (ln week: eye ß −0.74, p = 0.002; throat ß −0.39, p = 0.03; nose ß 0.64, p = 0.06).; No trend in prelab symptom severity over 10week course
Uba et al. (1989) (California); Panel study, 1984-1985. 103 of 142 medical students in a 7-mo anatomy class, meeting twice a wk for 4 hrs (September 1984–April 1985), mean age (range): 24.3 (21–33) years.; Outcome: Persistent symptoms: 103 students completed respiratory questionnaire (ATS) at the beginning (September 1984) and end of course (April 1985). Acute symptoms: 81/103 students completed different questionnaire after anatomy lab with formaldehyde exposure and after microanatomy lab (no formaldehyde) during Nov 1984. Order of questionnaires varied.; Exposure: Personal samplers (impingers) in the breathing zone.; TWA formaldehyde concentrations (N = 32 samples during different class periods over 7 months). Short-term samples (N = 16) for peak concentrations during dissection and observation. Dissecting room ventilated 24 hrs/d TWA concentrations: range, ≤ 0.05 (LOD) to 0.93 ppm (< 0.06 to 1.1 mg/m^3^).; During dissection: mean 1.9 ppm (2.3 mg/m^3^); range 0.1 to 5.0 ppm (0.12 to 6.1 mg/m^3^).; When observing dissection: mean 1.2 ppm (1.5 mg/m^3^); range 0.2 to 2.0 ppm (0.25 to 2.5 mg/m^3^).; Monthly average in September, October, and May: 0.6, 0.8, 0.1 ppm (0.74, 0.98, and 0.12 mg/m^3^).; Analysis: Symptom prevalence at beginning of course compared to end of course, paired analysis, McNemar’s test; symptom prevalence after lab with formaldehyde compared to lab with no formaldehyde, odds ratios, McNemar’s test paired samples; High confidence | Symptoms during lab session: symptom prevalence in anatomy lab (exposed) compared with microanatomy lab (unexposed) (N = 81)
| Symptom | Exposed | Unexposed | Odds Ratio
| Itchy eyes | 33 | 1 | 33*
| Watery eyes | 36 | 3 | 12*
| Burning eyes | 47 | 0 | infinite
| Burning nose | 19 | 0 | infinite
| Sore throat | 21 | 4 | 5.3**
| Sneezing | 10 | 1 | 10**
| Rhinorrhea | 13 | 3 | 4.3**
| Chest tightness | 4 | 0 | infinite
| Cough | 5 | 4 | 1.3
| Wheezing | 2 | 0 | infinite
| Dyspnea | 2 | 0 | infinite
| McNemar’s test paired samples, * p<0.001; **p<0.05
| Persistent symptoms (Number reporting symptoms only in September 1984 or only in April 1985)
| Symptom | Sept. 1984 | April 1985 | Odds Ratio
| Cough | 1 | 8 | 8.0*
| Phlegm | 4 | 9 | 2.3
| Chronic | 4 | 2 | 0.5
| bronchitis Chest | 9 | 0 | 0**
| illnesses Wheezing | 37 | 1 | 0.03**
| Wheezing with Dyspnea | 4 | 0 | 0***
| Dyspnea on exertion | 0 | 0 | -
| McNemar’s test paired samples, * p = 0.02; ** p <0.001; ***p = 0.05
Mori et al. (2016); (Japan); Cross-sectional study, Students (2^nd^ year), n=123 (98.4%) enrolled in afternoon gross anatomy classes, April–July 2013, mean age 22.9 years; compared to nonexposed 1^st^ year students, n=114 (91.9%), mean age 21.2 years. 75% males; Outcome: Questionnaire, 16 subjective symptoms, frequency never, sometimes, or often; administered April 2013 before, May 2013 during, and January 2014 6 mo after completion of course.; Exposure: Area samples at breathing height, 5 locations during class in May 2013 on same day questionnaires were completed. Mean (SD) 0.123 (0.025) mg/m^3^ (conversion by EPA).; Area sample, 5 locations during class on same day questionnaires were completed.; Mean (SD) 0.1 (0.02) ppm; Analysis: Regression of presence or absence of symptoms in relation to exposure group on day of survey, controlling for doctor-diagnosed allergies, sex and age; High confidence | Symptoms reported comparing exposed to unexposed on a day during gross anatomy class (OR (95% CI))
| Symptom | OR | 95% CI
| Eye soreness | 2.35 | 1.3–4.27
| Eye strain | 1.82 | 1.07–3.14
| Itchy eye | 0.75 | 0.43–1.31
| Dry eye | 1.11 | 0.63–1.96
| Tearing | 2.62 | 1.36–5.04
| Itchy nose | 1.76 | 1.01–3.06
| Nasal | 0.78 | 0.44–1.36
| Runny nose | 0.82 | 0.47–1.44
| Sore throat | 1.45 | 0.82–2.55
| Dry throat | 0.87 | 0.49–1.57
Kriebel et al. (2001) (Massachusetts); Panel study, 38 anatomy students (of 54 total) during 12-wk class meeting once per week, 2.5 hrs. Mean age 24.9 years, 23.7% male, 2 current smokers, 5 ex-smokers, 4 history of asthma; Outcome: Symptom questionnaires before and after each lab session. Scale of symptom intensity ranged from 0 (not at all) to 10 (very, very much).; Exposure: Continuous monitoring in 6 homogenous locations (LOD = 0.05 ppm [0.06 mg/m^3^). 12-min work-zone concentrations for each student calculated using sampling data and recorded work locations.; Geometric mean concentration over all lab sessions and participants: 0.7 ppm [0.9 mg/m^3^] (GSD 2.13) Peak 12 min concentration 10.91 ppm (13.42 mg/m^3^); Average ± SD concentration over all weeks and participants: 1.1 ± 0.56 ppm (1.4 ± 0.69 mg/m^3^); Concentrations decreased over 12-wk semester.; Analysis: Generalized estimating equation regression model accounting for lack of independence of repeated measures in individuals.; Medium confidence; Decline in attendance over time potentially based on exposure and outcome status. | Mean postlab intensity of eye, nose, and throat irritation decreased over semester.; Association of symptom intensity with exposure during lab & interaction with time (Percent change in intensity per ppm or ppm-weeks)
| | Recent exposure^b^ | Recent exposure x ln(week)^c^
| Eye Irritation | 1.22* | −0.35*
| Nose Irritation | 1.09* | −0.42*
| Throat Irritation | 0.81* | −0.36*
| ^*^ p <0.001 for significant deviation from slope = 0; ^b^Mean concentration during 2.5-hr lab; ^c^Interaction between recent exposure and natural log of week number, indicating declining strength of association with time.
Takahashi et al. (2007) (Japan) Panel study, 2002–2003. 143 medical students (68.5% male, 88.8% 20–24 years of age) who dissected cadavers 15 hours per week for 2 mos and 76 students who had taken same course 2 to 4 years earlier (68.4% male, 77.6% 20–24 years of age).; Outcome: Symptom questionnaire administered after 1^st^ day of exposure and at end of course.; Exposure: Area formaldehyde samples (> 10 min, 8 locations in room), upon opening of thorax, mean 2.12 ppm (SD 0.23), range 1.7–2.44 ppm (2.6 ± 0.28 mg/m^3^, range 2.13–3.05 mg/m^3^). Breathing zone samples (18/143 students), mean 2.4 ppm (SD 0.49), range 1.79–3.78 ppm; (mean 3.0 ± 0.61 mg/m^3^, range 2.24–4.72 mg/m^3^); Analysis: Prevalence after first exposure and at end of course compared, McNemar’s test; Medium confidence; Large gap between symptom ascertainment at end of course and exposure measurements. Selection, recruitment and participation was not reported. | Prevalence after first exposure and at end of course estimated from Figure 1 in the paper. Largest increase in symptoms (p<0.05) reported for eye soreness (from about 35% to about 68% on 1^st^ day versus end of course), lacrimation (12% to 60%), throat irritation (14% to 42%), eye fatigue (28% to 44%), rhinorrhea (17% to 35%), skin irritation (14% to 28%).
Takigawa et al. (2005); (Japan); Intervention study, purpose: Evaluate installation of a ventilation system between phases and effects on formaldehyde concentrations and symptoms. 2 phases; 1st phase: 78 volunteer anatomy students in 2001 (mean age 21.6 years); 2^nd^ phase: 79 volunteer anatomy students 3 years later in 2004 (mean age 21.7 years).; Outcome: Self-administered questionnaires on health complaints before and during each 2-mo course. Symptom frequency: 1 (never), 2 (scarcely), 3 (sometimes), and 4 (always). Symptom change index: Symptom frequency score during session subtracted from score before course.; Exposure: Area formaldehyde samples (>10 min, 9 locations in room); upon opening of thorax (represents highest concentration over 2 mos).; Phase I: Median (range) 2.59 (2.1–3.0) mg/m^3^ (concentration reported as 0.259 mg/m^3^ in Table 3 of the paper must be an error).; Phase II: Median (range) 0.729 (0.291–0.971) mg/m^3^ Personal samples (measured with gas sampler on 24 students in first phase (42–962 min) and 46 in second phase (100–540 min)):; Phase I: Median (range) 3.313 (2.238–8.909) mg/m^3^; Phase II: Median (range) 0.878 (0.396–3.386) mg/m^3^; Analysis: Symptom change index, 1^st^ and 2^nd^ phases compared; Mann-Whitney test, p <0.05.; Medium confidence; Uncertainty regarding impact of smoking on sensitivity of response to intervention | Symptom change indexes for 8 of 25 measured symptoms were significantly less comparing the second phase results with the first phase results.; Symptom Change Index
| | Symptom | 1^st^ (N=78) | 2^nd^ (N=79)
| Skin | Eczema | 0.13 | −0.09
| Eye | Itchy | 0.74 | 0.27
| | Irritated | 0.96 | 0.52
| | Watery | 1.42 | 0.46
| | Poor vision | 0.17 | −0.27
| Nose | Itchy | 0.67 | 0.22
| | Changed sense smell | 0.18 | 0.33
| Throat | Sore | 0.69 | 0.22
Wantke et al. (2000) (Austria); Panel study, 27 medical students, participants in Wantke et al. (1996) enrolled in a 2^nd^ dissection class, 55.6% male; Outcome: Symptoms standardized questionnaire at beginning, in middle, and at end of 10-wk course. Daily symptom cards during class; Exposure: Continuous measurements for formaldehyde and phenol at 2 locations during lab, exposures for 43 d Formaldehyde Mean 0.265 ± 0.07 mg/m^3^, range 0.133–0.410 mg/m^3^,; Phenol Mean 4.65 ± 2.96 mg/m^3^, range 0.09–11.8 mg/m^3^; Analysis: Prevalence in November and December compared to October, McNemar exact test; Medium confidence; Uncertainty regarding selection and recruitment details.; See Wantke et al. (1996b) | Symptom prevalence was not correlated with smoking, or type I allergy, complaints of dizziness occurred only in males; Prevalence of Symptoms at Beginning, Middle (5 Wks) and End (10 Wks) of Course
| Symptoms | Before | Middle | End
| Burning eyes | 0.111 | 0.481** | 0.333*
| Sneezing | 0.074 | 0.037 | 0.037
| Nosebleed | 0.185 | 0.111 | 0.185
| Cough | 0.074 | 0.148 | 0.074
| Shortness of breath | 0 | 0.185 | 0.037
| *p <0.05, **p <0.01
Wantke et al. (1996b) (Austria); Panel study, 1995. 45 medical students enrolled in 1^st^ dissection class, 51.1% male, age 20.9 years, 3 hr sessions, 5 d/wk for 4 wks; Outcome: Symptoms, standardized questionnaire at beginning and at end of 4-wk course; Exposure: Continuous measurements for formaldehyde, 2 locations during lab; Mean 0.124 ± 0.05 ppm, range 0.059–0.219 ppm; No sampling for phenol; Analysis: Compared symptom prevalence during course to before, McNemar exact test; Low confidence; Low participation, possibility of selection bias away from null; Potential recall issues – symptoms for previous week Potential for differential recall of symptoms. s | Prevalence of Symptoms During 4 Wk Course
| Symptoms | Before | During | p-Value
| Burning eyes | 0.133 | 0.289 | < 0.02
| Sneezing | 0.244 | 0.089 | NS
| Nosebleeds | 0.244 | 0.044 | NS
| Cough | 0.044 | 0 | NS
| Shortness of breath | 0 | 0.022 | NS
| Symptom prevalence was not correlated with gender, smoking, or type I allergy.
Chia et al. (1992) (Singapore); Cross-sectional study. 1^st^ year medical students in anatomy lab, 150 of 164 total (91.5%); referent 189 3^rd^ and 4^th^ year medical students, no recent formaldehyde exposure; matched on age, sex, and ethnicity.; Outcome: Symptoms during previous 4 wks of anatomy course (twice per wk, 2.5 hr (or other activities for referent), assessed via a modified MRC standardized questionnaire; Exposure: Area samples at dissecting tables, n=6, collected on two occasions, Mean (SD) 0.5 ppm (0.08), range 0.4–0.6 ppm; Personal samples, n=14 students, duration 2.5 hrs, Mean (SD) 0.74 (0.18), range 0.41–1.2 ppm; LOD 0.05 ppm; Analysis: Symptom prevalence in exposed compared to referent; Low confidence; Questions about dissimilarity of 1st and 4th year students and potential for recall bias during previous 4 weeks of course. No measurements of formaldehyde among referent group. | Prevalence of Symptoms
| Symptom | Exposed (n = 150) | Referent (n = 189) | p-Value
| Decreased ability to smell | 0.127 | 0.032 | 0.002
| Eye irritation | 0.8 | 0.132 | < 0.001
| Throat irritation | 0.313 | 0.138 | < 0.001
| Dry mouth | 0.18 | 0.058 | < 0.001
| No statistically significant difference for other symptoms (cough with mucus, chest tightness, chest pain, and breathlessness) (data were not reported).
Fleisher (1987) (New York); Cross-sectional study; 1st year medical students (N = 89) (43.6% of total 204 surveyed) (71% male) in gross anatomy course (formaldehyde exposed). Referent: Same students (n=60) (72% male) in pathology/microbiology laboratory six months later. 98.9% of all students attended 75–100% of all lab sessions.; Outcome: Symptoms questionnaire one month after end of course.; Symptom frequency: all of the time, some of the time, rarely or never.; Exposure: Area formaldehyde measurements in 6 anatomy labs, one day during semester, 1983; sampling time 188–222 minutes. Personal breathing zone samples (3M Diffusion), 2 instructors, sampling time 180–190 min.; Area samples:; Drager tubes (all labs): <LOD (1 ppm); NIOSH method (3 labs): LOD (0.02 ppm), 0.03, 0.59 ppm;; Breathing zone: 0.18 and 0.69 ppm;; Analysis: Within person comparisons; t-test comparing mean symptom scores; Low confidence; Low response to both questionnaires and selection potential; with potential for symptoms to contribute to motivation to participate. Temporal gap in symptom response reduced recall accuracy potential. | Symptoms prevalence (% reporting symptom all or some of the time) among 38 students responding to both questionnaires (N=38)
| Symptom | Anatomy | Path/Micro
| Eye Irritation | 68.4^*^ | 21.0
| Nose Irritation | 61.1^*^ | 13.1
| Sneezing | 37.8^*^ | 15.8
| Tightness in chest | 11.1 | 2.6
| Shortness of breath | 8.3^*^ | 0.0
| Cough | 28.6^*^ | 5.3
| Throat Irritation | 38.9^*^ | 7.9
| Sinus problems | 35.1^*^ | 5.3
| ^*^ p < 0.05

GSD = geometric standard deviation; MRC = Medical Research Council; NIOSH = National Institute of Occupational Safety and Health; ND = not detected.

Table C-23 Summary of epidemiology studies of occupational exposures to formaldehyde and human sensory irritation

(Reference), study design, exposure levels | | Results
Neghab et al. (2011) (Iran); Prevalence study, 70 male exposed workers with ≥2-year history of exposure at a melamine-formaldehyde resin producing plant (mean (SD) age: 38.2 (8.4) years; mean (SD) work duration 13.2 (7.8) years. 24 male, healthy referent employees with no current or history of exposure to formaldehyde or other respiratory toxicants (mean (SD) age: 40.0 (8.2) years); mean (SD) work duration 14.5 (8.1) years. 100% participation.; Outcome: Respiratory symptoms ascertained via interview using standardized questionnaire (ATS).; Exposure: Area samples (40-minute sampling time) in 7 workshops (N=7) and offices (N=1); Formaldehyde concentration: ppm, mean (SD): Exposed: 0.78 (0.40) (0.96 (0.49) mg/m^3^); Referent: nondetectable; Analysis: Symptom prevalence compared; Medium confidence; Healthy survivor bias Potential for healthy survivor bias with attenuation in measure of association. | | Prevalence Respiratory Symptoms:
| | Symptom | Exposed | | | Referen
| | | | | | t
| | Cough | 20%* | | | 0%
| | Phlegm | 28.6%* | | | 0%
| | Chest tightness | 52.9%* | | | 0%
| | *p < 0.05
Holness and Nethercott (1989) (Toronto, Canada); Prevalence study, 84 of 97 selected funeral service apprentice workers from funeral homes selected by the Metropolitan District Funeral Director’s Association (mean (SD) age 32.1 (11.1) years, 89% male, work duration 8.2 years (SD 9.9)). 38 service volunteers and paid student volunteers as referent subjects similar in age to the apprentices (mean (SD) age 28.7 (12.7) years, 84% male, work duration 7.2 years (SD 11.9)).; Outcome: Questionnaires (ATS) administered before and after an embalming procedure.; Exposure: Area samples (N=2) during each embalming procedure, mean sampling duration (range): 85 minutes (30–180 minutes).; Mean (SD) formaldehyde: Exposed: 0.36 (0.19) ppm (0.44 (0.23) mg/m^3^)^a^, range 0.08–0.81 ppm. Autopsied cases 0.44 ppm.; Average levels were 0.21 ppm when ventilation units were in operation.; Referent: 0.02 ppm (0.025 mg/m^3^)^a^; Analysis: Differences evaluated using logistic regression analysis controlling for smoking (pack-years).; Medium confidence; Groups selected from different source populations Differences in source populations for exposed and referent groups lead to uncertainty in comparability, with no consideration of potential confounding. | | Prevalence elevated for 12 of 13 eye, URT, respiratory and cutaneous symptoms, but 5 were significantly higher compared with referent: chronic bronchitis (20% vs. 3%, p = 0.035), shortness of breath (20% vs. 3%, p = 0.043), nasal (44% vs. 16%, p = 0.003) and eye (42% vs. 21%, p = 0.026) irritation and past skin problem (42% vs. 13%, p = 0.003).
Horvath et al. (1988) (Wisconsin); Prevalence study, 109 of 159 workers at a particleboard manufacturing plant (71% participation); 57% male; mean age 37.4, SD 11.7 years; Mean duration of employment 10.3 years (1 – 20 years); Referent: 254 of 300 workers at 2 food plants (44% male; mean age (SD): 34.2 (10.6) years.; Outcome: Respiratory symptoms questionnaire (American Thoracic Society, ATS) completed before and after monitored work shift. Intensity assessed by subjects with visual analog scale.; Exposure: Personal and area samples; 8-hr, TWA concentrations measured on each worker on the day of examination. In the particleboard plant, TWA values averaged 1.04 mg/m^3^; range 0.26 to 4.4 mg/m^3^. In the food plants, TWA values averaged 0.08 mg/m^3^, range 0.03 ppm to 0.12 ppm).; Other agents sampled in particleboard or molded products plant. | | Symptom Prevalence While at Work; Reported in Preshift Questionnaire:
| | Symptom | Exposed | | | Referen
| | | | | | t
| | Nose/throat irritation | 43.9%* | | | 13.0%
| | Eye irritation | 49.5%* | | | 24.0%
| | *p < 0.05
| | Symptom Prevalence Reported at End of Shift:
| | Symptom | Exposed | | | Referen
| | | | | | t
| | Throat | 22.0%* | | | 3.9%
| | sore/burning Cough | 34.9%* | | | 18.9%
| | Phlegm | 26.6%* | | | 9.8%
| | Nose burning | 28.4%* | | | 2.0%
| | Stuffy nose | 33.9%* | | | 14.2%
| | Itching nose | 21.1%* | | | 7.9%
| | Eyes burning | 39.5%* | | | 9.1%
| | Eyes itching | 19.3%* | | | 7.1%
| | *p <0.05
Compound | Mean (Range) | Intensity (visual analogue scale, 0 – 100) for burning eyes, mean (SD) 47 (27); Shortness of breath (8.3 vs. 5.1%), wheezing (3.7 vs. 2.8%), and difficulty breathing (6.4 vs. 2.0%) were not significantly increased.; Dose-response: formaldehyde a significant predictor of cough, chest complaints, phlegm, burning nose, stuffy nose, burning eyes, itchy nose, sore throat, and itchy eyes in multiple regression models; coefficients were not reported.
Total particulates^a^ | 0.38 (0.25-4.4) mg/m^3^
Respirable particulates | 0.11 (0.025-1.06) mg/m^3^
Phenol | 0.15 (0.11-0.26) ppm
Carbon monoxide | 7.35 (3.0-11.0) ppm
Sodium hydroxide | 0.4 – 0.21 mg/m^3^
Nitrogen dioxide | ND
^a^Total particulates in food plants were 0.5 and 0.42 mg/m^3^.; Analysis: Prevalence compared using chi-square statistic. Doseresponse of end of shift symptoms evaluated using multiple regression models.; Medium confidence; Uncertain whether analyses adjusted for age or gender, although groups were compared and differences were not large.
Löfstedt et al. (2011b); Prevalence study. Sweden; 3 brass foundries producing cores using Hot Box method. 43 of 48 exposed workers; 69 of 84 referents working outside core-production and die-casting halls; not exposed to chemicals. Prevalence of “ever” asthma or childhood allergy lower in exposed than in referent (9% and 19%, respectively versus 14% and 35%, respectively, p<0.05); Outcome: Self-report, questionnaire; existence of symptoms during prior week; nasal signs; Exposure: Individual measurements. Monoisocyanates: Mean of 4–5 5-min samples randomly distributed over entire shift.; Formaldehyde: sampling over entire 8-hr shift; Categorized low and high using LOD as cut-point (LOD not reported).; Mean 0.51 mg/m^3^, SD 0.049 mg/m^3^, range 0.013–0.19 mg/m^3^; Low (↑) confidence; Could not distinguish effect of formaldehyde from those of other irritants that were strongly associated with symptoms; Questionnaire not described. Potential for information bias (reduced recall accuracy); higher proportion of asthma or allergy among referents raises potential healthy worker survival. | | Associations of ocular and nasal symptoms within the previous week and nasal signs with formaldehyde exposure
| | | Referen t (n=68) | | Low (n = 30) | | High (n = 12)
| | Any nasal symptoms | 1.0 | | 4.3 (1.7–11.2) | | 4.7 (1.2–19.1)
| | Nasal signs – dry mucosa | 1.0 | | 2.8 (1.1–6.9) | | 2.8 (0.8–10.2)
| | Irritated eyes | 1.0 | | NR* | | 6.3 (1.4–28.4)
| | NR: not reported
| | Nasal symptoms included discharge, itch, sneezing and congestion; ICA and MIC also associated with these nasal endpoints, nasal symptoms OR 3.9 low and 5.0 in high exposed; nasal signs OR 4.5 low and 1.9 high exposed
Alexandersson et al. (1982); Alexandersson and Hedenstierna(1989) (Sweden); Prevalence study, 1980, Employees at carpentry works (N=47) for > 1 year, regularly exposed to formaldehyde, and working on the study day, mean age (± SE) 35 (1.8) years, 49% smokers, duration employment 5.9 years. Referent (N=20) not exposed to formaldehyde or other lung irritants, employed at the same plant, mean age (± SE) 35.3 (2.3) years. Asthmatics excluded. Follow-up 5 years later (1984), 34 exposed and 18 referents; 21 remained exposed, 13 transferred to tasks with no exposure to irritants.; Outcome: Interviews using standardized questionnaire focused on nose, eyes, upper airways, and lungs, chronic bronchitis defined by British Medical Research Council.; Exposure: 1980 study: Personal samplers for formaldehyde, terpenes, and dust, N=31, duration 6–7 hr/d; Mean concentration (range): formaldehyde 0.47 mg/m^3^, 0.05–1.62 mg/m^3^, terpenes 0 (0–9) mg/m^3^, dust 0.5 (0.3–0.7) mg/m^3^; 1984 study: 3–4 15 min samples per person in the exposed group, estimated TWA; Mean TWA concentration (± SD): formaldehyde 0.50 (0.12) mg/m^3^; Mean Peak concentration (± SD): formaldehyde 0.69 ± 0.68 ppm; Analysis: Prevalence of symptoms while at work, change from 1980 to 1984, chi-square; Low confidence; Evidence of healthy survivor bias; confounding by smoking. | | Symptom Prevalence at Work, 1980 (%)
| | | Exposed | | | Referent
| | Eye | 74 | | | 0
| | Nose, Throat | 36 | | | 0
| | Symptom Prevalence at Work, 1984 (%)
| | | Ex-posed | | Trans-posed | | Referent
| | Eyes
| | Smarting | 45 | | 30 | | 0
| | Itching | 40 | | 20 | | 17
| | Running | 60 | | 30 | | 12
| | Nose
| | Running | 30 | | 10 | | 12
| | Dryness | 15 | | 0 | | 6
| | ↓ Smell | 0 | | 0 | | 0
| | Change from 1980 to 1984 not statistically significant, p >0.05
Herbert et al. (1994); Prevalence study, 99 oriented strand board (OSB) workers (exposed, 98% participation), mean age 35.4 years, 51.5% smokers; work duration 5.1 years; 165 oil/gas field plant workers (not exposed to formaldehyde or oil and gas vapors) from same geographic area (82% participation), mean age 34.9 years, 27.9% smokers, work duration 10 years. Excluded 14 workers in referent with hydrogen sulfide exposure.; Outcome: Respiratory symptoms ascertained via interview using standardized questionnaire.; Exposure: Time weighted average formaldehyde and dust concentrations based on 21-hr continuous sampling in the breathing zone at 5 work sites on 2 separate days.; Formaldehyde: range 0.07–0.27 ppm (0.09–0.33 mg/m^3^). Dust mean: 0.27 mg/m^3^, 2.5 µm diameter; Analysis: Symptom prevalence compared; Low confidence; Different prevalence smoking and duration of employment between exposed and referent; no adjustment in analyses. | | Prevalence Respiratory Symptoms (relevant to URT irritation):
| | Symptom | Exposed | | | Referent
| | Usual Cough | 24.5%* | | | 11.1%
| | Usual Phlegm | 31.3%* | | | 13.3%
| | Chest tightness | 43.4%* | | | 22.8%
| | *p < 0.05
Holmström et al. (1991); Sweden; Prevalence study, Group 1: 16 persons exposed to medium density fiberboard (MDF) dust for at least 30% of the workday, mean age 44.1 years, 100% male, 38% smokers. Group 2: 29 exposed to other types of wood dust, mean age 39.3 years, 86.2% male, 31% smokers. Group 3 (Referent), 36 governmental clerks living in same village as chemical plant, mean age 39.9 years, 47.2% male, 28% smokers. (Groups 2 and 3 same as for (Holmström and Wilhelmsson, 1988); Outcome: Symptom prevalence; Questionnaire and medical examination; Exposure: Personal exposure measurements stable through year, average 0.2–0.3 mg/m^3^, peaks seldom > 0.5 mg/m^3^, Formaldehyde Concentration, mean; MDF 0.26 mg/m^3^, range 0.17–0.48 mg/m^3^; Wood dust 0.25 mg/m^3^, range 0.3–1.0 mg/m^3^; Referent 0.09 mg/m^3^; Analysis: Exposed compared to referent; prevalence rate difference, 95% confidence intervals; Low (↓) confidence; Potential for healthy survivor bias with attenuation in measure of association.; groups selected from different source populations; Questionnaire not described. Potential confounding and no adjustment in analyses. | | Rate Difference (%) in Symptoms, Exposed versus Referent
| | Symptom | MDF | | | Wood Dust
| | | % | 95% CI | | % | 95% CI
| | Nasal | 66 | 47, 85 | | 3 | −20, 26
| | Eye | 38 | 13, 64 | | 1 | −1, 13
| | Throat | 19 | −3, 42 | | 4 | −8, 18
| | Lower airway | 36 | 9, 63 | | 3 | −14, 21
| | Relief from symptoms during weekends in 80% in MDF group and 67% in wood dust group; and during vacations.
Alexandersson and Hedenstierna (1988); Supplemental: Alexandersson (1988) (Sweden); Prevalence study, 38 exposed employees working with acidhardening lacquers for the previous 12 mos (mean age (SD): 34 (10) years, mean duration employment 7.8 years) and at work on the study day. 18 referent employees at the same company (mean age (SD): 37 (9) years). Asthmatics excluded.; Outcome: Interviews regarding irritation of eyes, nose, throat, lungs and bronchi were conducted using a standardized questionnaire.; Exposure: Formaldehyde measurements in the breathing zone, 3–4 15 min samples per person in the exposed group. No formaldehyde measurements reported for referent group. Formaldehyde TWA: 0.40 mg/m^3^, range: 0.12–1.32 mg/m^3^. Peak concentration (15 min): 0.70 mg/m^3^, range: 0.14–2.6 mg/m^3^.; Additional measurements of solvents and dust (4 hr); Analysis: Group comparisons, chi-square statistic; Low confidence; Potential for healthy survivor bias with attenuation in measure of association. Confounding and no adjustment in analyses. | | Symptom Prevalence at Work
| | | Exposed | | | Referent
| | | N (%) | | | N (%)
| | Eye | 25 (65.8) | | | 3 (16.7)
| | Nose, Throat | 15 (39.5) | | | 0
| | Dyspnea | 4 (10.5) | | | 0
| | Chest oppression | 4 (10.5) | | | 0
| | Cough | 2 (5.3) | | | 0
Wilhelmsson and Holmstrom (1992); Holmström and Wilhelmsson (1988) (Sweden); Prevalence study, three test groups chosen by the Swedish Board of Occ. Safety and Health. Group 1: 70 exposed to formaldehyde at a chemical plant (resins and impregnation of paper for laminate production), mean age 36.9 years, 87% male, work duration 10.4 year (SD 7.3), range 1–36 year. Group 2: 100 exposed to wood dust and formaldehyde, mean age 40.5 years, 93% male, work duration 16.6 year (SD 11.3), range 1–45 year. Group 3 (referent), 36 governmental clerks living in same village as chemical plant, mean age 39.9 years, 56% male, work duration 11.4 (SD 5.4), 4–18 year.; Outcome: Questionnaire and medical examination, excluding upper airway infections. Atopics identified and analyzed separately from nonatopics based on a laboratory test utilizing the allergosorbent principle.; Exposure: Breathing zone (personal samplers, 1–2 hrs), mean, range 1985: Group 1: 0.26 (SD 0.17) mg/m^3^; 0.05–0.50 mg/m^3^. Group 2: 0.25 (SD 0.05) mg/m^3^; 0.2–0.3 mg/m^3^ and 1.65 mg/m^3^ for wood dust.; Group 3 Referent: 0.09 mg/m^3^; Cumulative exposure (dose-years) based on JEM; No occupational exposure to solvents; other agents (phenol, ammonia, epichlorhydrin, methanol, and ethanol) less than 1% above PEL.; Analysis: Compared symptom prevalence across exposure groups, chi-square; Low (↓) confidence; Potential for healthy survivor bias with attenuation in measure of association.; groups selected from different source populations; Questionnaire not described. Potential confounding and no adjustment in analyses. | | Significantly increased symptom prevalence reported in formaldehyde exposed groups
| | | Exposure Group
| | | 1 | | 2 | | 3
| | Nasal | 64%* | | 53%* | | 25%
| | Eye | 24%* | | 21% | | 6%
| | Deep airway discomfort | 44%* | | 39%* | | 14%
| | *p < 0.05
| | No significant difference between atopics vs. nonatopics in symptom prevalence.; Majority reported symptoms did not change over time
Kilburn et al. (1985a) (Los Angeles); Prevalence study, 76 female histology technicians in 23 hospitals & 2 labs (exposed), 97% of eligible, mean (SD) age 40.8 (11.6) years, work duration 12.8 (9.3) years; 56 women in referent (secretaries and clerks in same institutions) matched with 40 of the technicians for age, cigarette smoking, and ethnicity, mean (SD) age 39.5 (10.5) years.; Outcome: Questionnaire for symptoms; composite experience for previous months or years; Exposure: Environmental samples for formaldehyde, xylene, toluene, and chloroform by regional NIOSH laboratory in 10 of 25 labs; 1–4 hrs sampling time.; Collected information on exposures, work practices and ventilation.; Tissue specimen preparation,; Formaldehyde 0.2–1.9 ppm (0.25–2.34 mg/m^3^)^a^; rooms with tissue processors, xylene 8.9–12.6 ppm, chloroform 2–19.1 ppm; Staining and cover-slipping, xylene 3.2–102 ppm, toluene 8.9–12.6 ppm.; Clerical offices Formaldehyde ND; xylene ND; Analysis: Prevalence by hours formaldehyde exposure and xylene exposure (statistical analyses not provided).; Low confidence; Extended time period for symptom reporting may have reduced accuracy of recall; incomplete matching; results of statistical analyses were not reported. | | Formaldehyde, xylene and toluene concentrations were not correlated with symptoms (data not shown).
| | Symptom Prevalence (%) by Duration of Formaldehyde Exposure (hours)
| | Symptom | Ref | Formaldehyde (Hours) | | | >4 hours^1^ Xylene: # Slides Cover slipped
| | | | 0 | 1–3 | >4 | <100 | <100
| | Number | | 7 | 22 | 47 | 27 | 20
| | < odor^2^ | 5 | 14 | 32 | 32 | 22 | 45
| | Eye | 20 | 28 | 59 | 66 | 63 | 70
| | Throat | 12 | 14 | 36 | 49 | 37 | 65
| | Dry Mouth Cough | 20 | 43 | 50 | 47 | 41 | 55
| | Dry | 9 | 14 | 23 | 34 | 22 | 50
| | Mucous | 9 | 14 | 0 | 19 | 7 | 35
| | Blood | 0 | 0 | 0 | 8.5 | 4 | 15
| | Chest
| | Tight | 5 | 14 | 27 | 40 | 26 | 60
| | Pain | 5 | 14 | 23 | 40 | 37 | 40
| | ^1^ Xylene exposure among those with >4 hrs exposure to formaldehyde.
| | ^2^ Decreased odor perception.

CI = confidence interval; MDF = medium density fiberboard; OR = odds ratio; OSB = oriented strand board; SE = standard error.

a Concentrations reported by authors as ppm or ppb converted to mg/m^3^.

## C.5 PULMONARY FUNCTION (SUPPORTING INFORMATION FOR HAZARD)

The acute, controlled human exposure studies involving healthy or asthmatic volunteers generally did not observe changes, even at high concentrations, although two studies by one research team observed small decrements (<5%) when longer exercise components (15 minutes) were included (see Appendix C.5.1). Studies using shorter exercise components (8–10 minutes) reported no changes. Two studies of asthmatic volunteers included an allergen challenge (dust mites, pollen), which resulted in a hyperreactive bronchial response at a lower challenge dose associated with formaldehyde exposure compared to clean air in one study that imposed mouth breathing (nose clips) (see Section 3.2.4 of the Toxicological Review). The studies of occupational groups or dissection labs that measured pulmonary function declines over the course of the workday or lab (Appendix C.5.2) provide support for formaldehyde-related effects over a short-term exposure; however, many did not account for diurnal changes, limiting the interpretation of these results.

### C.5.1 Controlled human exposure studies

Formaldehyde exposures (0.62–3.7 mg/m^3^), lasting from minutes to up to 5 hours, have not induced pulmonary function deficits in healthy, nonexercising volunteers in controlled human exposure studies (see Appendix B.3.3 for study evaluation summaries). The studies exposed small numbers (<25) of diverse individuals, often including males and females of varying age, and two included current smokers [31% of participants in the study described in Andersen (1979) and Andersen and Molhave (1983), and 13% of the participants in Schachter et al. (1987)]. In some studies, the variation around the mean change in lung function was quite large suggesting that the response to exposure was large in some individuals, and in others, the response was small (Witek et al., 1986; Schachter et al., 1986b; Schachter et al., 1987).

In contrast to the studies of exposure without exercise, small but statistically significant deficits in pulmonary function (e.g., decreased FEV_1_, FVC, FEV_3_, FEF_25–75_, specific airways conductance) during formaldehyde exposures of 2.5 or 3.7 mg/m^3^ were reported in two studies from one research group that included two or more 15-minute exercise regimens within the study protocol (Green et al., 1987; Green et al., 1989). Although the average decrease in lung function after 55 minutes of exposure was considered small by the authors (2.2–3.3%), 5 of the 38 subjects individuals exhibited clinically significant deficits defined as a 10% or greater change, even after only 2 hours of exposure, suggesting that individual susceptibility may be an important consideration (Green et al., 1987). These effects were not seen, however, in studies with shorter exercise segments [8–10 minutes; (Schachter et al., 1986b; Schachter et al., 1987; Kulle et al., 1987)].

One of two studies of asthmatic volunteers that included an allergen challenge (dust mites, pollen), reported a hyperreactive bronchial response triggered at a lower challenge dose associated with formaldehyde exposure compared to clean air. This study included the use of nose clips to impose mouth breathing (Casset et al., 2006) (see Section 3.2.4 of the Toxicological Review).

Table C-24 Formaldehyde effects on pulmonary function in controlled human exposure studies

Study and design | Results
Medium Confidence (Randomized, results fully reported)
References: Witek et al. (1986); Schachter et al. (1986a); Population: N = 15 healthy, age 18–35 years, N=15 asthmatic, age 22 ± 5 years, all nonsmokers.; Exposure: 40 min; Clean air and 2 ppm (2.46 mg/m^3^)^a^; Protocol: Random assignment to order of exposure, double blinded. Two dose levels, four exposure conditions, 2 d at rest and 2 d with exercise segment (10 min, at 10 min into the exposure period), separated by 4 d. Testing at baseline, and at 4 times during 40-min exposure, and 10 and 30 min postexposure.; Change from baseline tested using “standard test” and Bonferroni adjustment. | No decrements in percent change from baseline in resting protocol; FVC, FEV_1_, MEF50% (shown below), MEF40% or R_aw_. Exercise protocol showed decrement in MEF50% 30 min after exposure end.; Percent Change from Baseline (Mean±SD)
| | Clean Air | 2 ppm
| FVC (L) | During exposure (@ 40 min.)
| rest | −1.14 ± 4.8 | −0.99 ± 3.5
| exercise | 1.6 ± 7.7 | 0.17 ± 6.2
| FEV_1_ (L)
| rest | −0.41 ± 5.0 | 1.65 ± 4.5
| exercise | 4.87 ± 8.3^*^ | 4.56 ± 5.3^**^
| MEF50% (L/sec)
| rest | 2.74 ± 4.4 | 7.4 ± 5.0^*^
| exercise | 8.72 ± 12.6 | 8.8 ± 8.1^**^
| FVC (L) | 30 min. postexposure
| rest | 0.31 ± 5.1 | 1.75 ± 3.5
| exercise | −2.53 ± 5.4 | −0.25 ± 5.6
| FEV_1_ (L)
| rest | 0.5 ± 4.7 | −1.15 ± 5.3
| exercise | −0.37 ± 4.5 | 1.76 ± 4.91
| MEF50% (L/sec)
| rest | −0.87 ± 5.4 | 2.65 ± 8.1
| exercise | 1.07 ± 5.3 | −5.74 ± 5.4^**^
| ^*^ p <.05; ^**^ p <.01
Reference: Schachter et al. (1987); Population: N = 15 healthy hospital laboratory workers routinely exposed to HCHO as part of their job, age 32 ± 11.3 years, 33.3 % male, N = 2 smokers.; Exposure: 40 min; clean air and 2.0 ppm (2.46 mg/m^3^)^a^; Protocol: Random assignment to order of exposure, double blinded.; Two dose levels, four exposure conditions, 2 d at rest and 2 d with exercise. One 10-min exercise segments at 5 min into the 40-min exposure period. Testing at baseline, and at 4 times during exposure, and 10 and 30 min postexposure. Percent change from baseline tested using one sample t-test with Bonferroni adjustment. | Percent Change from Baseline (Mean±SD)
| | Clean Air | 2 ppm
| FVC (L) | During exposure (@ 40 min.)
| rest | −1.64 ± 5.67 | −1.30 ± 3.64
| exercise | −1.32 ± 6.94 | −1.60 ± 6.03
| FEV_1_ (L)
| rest | −1.25 ± 5.25 | −2.05 ± 3.62
| exercise | −0.67 ± 6.33 | −1.56 ± 6.02
| FVC (L) | 30 min. postexposure
| rest | 0.68 ± 4.13 | −0.54 ± 2.51
| exercise | 0.30 ± 4.58 | −0.07 ± 4.25
| FEV_1_ (L)
| rest | 1.94 ± 5.85 | −0.95 ± 3.0
| exercise | 0.62 ± 3.81 | 0.23 ± 4.2
Reference: Green et al. (1987); Population: n = 22, mean age 26.9 ± 3.6 year, nonsmoking, no history of allergies or hay fever; gender not reported.; Exposure: 60 min, clean air or 3.01 ± 0.01 ppm [3.7 ± 0.01 mg/m^3^]^a^; Protocol: Random assignment to order of exposure; single blinded. Two 15-min exercise segments at 15 and 45 min into the 60-min exposure period. Testing before and during exposure period (approximate 15 min intervals); paired t-test comparing ratio of exposed value at time(n) to time(0) to ratio of clean air value at time(n) to time(0). | Declines evident at 47 min, Statistically significant decrements measured in several endpoints at 55 min.; Absolute values at 55 min exposure
| | Clean air | 3 ppm
| FVC | 5.04 ± 0.15 | 4.92 ± 0.15*
| FEV_1_ | 4.29 ± 0.12 | 4.15 ± 0.13*
| FEV_3_ | 4.93 ± 0.15 | 4.80 ± 0.15*
| FEF_25-75_ | 4.74 ± 0.25 | 4.56 ± 0.29
| *p < 0.02, paired t-test
Reference: Green et al. (1989); Population: N = 24, 14 women and 10 men, age 18–35 years, nonsmoking, no history of asthma, no medications, FVC >80%, FEV/FVC >75%.; Exposure: 2 hr, clean air, 3 ppm [3.69 mg/m^3^]^a^, 0.5 mg/m^3^ ACA (activated aerosol carbon), 3 ppm plus 0.5 mg/m^3^ ACA.; Protocol: Randomized block design with 4 2-hr exposure conditions, one per week; double blinded. Four 15-min exercise segments at 15, 45, 75, and 105 min into the 2-hr exposure period. Spirometric testing before and during exposure period (5 times). PEF at 2 hrs, and hourly intervals for 8-hrs postexposure, and at 12 and 16 hrs postexposure. | Results presented in graphs for FEV_1_, FVC, FEF_25-75_, and FEV_3_. During exposure to formaldehyde + ACA, statistically significant changes were measured in FVC and FEV_3_ at several intervals and decreased SG_aw_ was measured at the end of exposure; magnitudes of the changes were less than 10% of baseline. No statistically significant (p >0.05) effects were observed on FVC, FEV_1_, or FEV_3_, at any of 5 intervals during 2-hr exposures; for formaldehyde only exposure, statistically significant decrements were observed for FEF_25-75_ and SGaw at 50 and 80 min, magnitudes of the changes were 3–5%, compared with baseline.
Low Confidence (Incomplete reporting of results, or blinding not described with multiple exposure levels)
References: Andersen (1979); Andersen and Molhave (1983); Population: N = 16 healthy students, age 30–33, 68.8 % male, 31.2% smokers; Exposure: 5 hours; 0.3, 0.5, 1.0, and 2.0 mg/m^3^; Protocol: Formaldehyde exposure order determined by Latin square design; blinding not described. Groups of 4 over 4 d; testing before (during 2 hrs clean air) and 2 times during exposure. No exercise component. | No change in FVC, FEV_1_, or FEF_25-75_; data presented in graphs; Visual inspection indicates decrease in VC at 1 and 2 mg/m^3^, FEF_25-75_ at 0.5 mg/m^3^ (not statistically significant).
Reference: Kulle et al. (1987); Population: Group 1 (N = 10), Group 2 (N = 9), nonsmoking healthy, age 26.3 ± 4.7 years, 53% male.; Exposure: 3 hr, Group 1: 0.0, 0.5, 1.0, or 2.0 ppm at rest (0.0, 0.62, 1.23, 2.46 mg/m^3^)^a^ at rest, and an additional 2.0 ppm with exercise; Group 2: 0.0, 1.0, or 3.0 ppm (0.0, 1.23, or 3.69 mg/m^3^), and an additional 2.0 ppm with exercise.; Protocol: Exposure order randomly assigned; blinding not reported. 3-hr exposures each week, at same time on 5 occasions. 8-min exercise segment every half hour during 2 ppm exposure. Pulmonary function tests (FVC, FEV_1_, FEF_25-75_ and SGaw) at 0, 30, 60, 90, 120, 150, and 180 min during exposure, and 24 hrs postexposure. | No change in pulmonary function (means by testing time, no SD presented).
Reference: Lang et al. (2008); Population: N = 21, age 19–39 years, nonsmoking, healthy volunteers.; Exposure: 4 hours, clean air, 0.15, 0.3 and 0.5 ppm (0.0, 0.19, 0.37, and 0.62 mg/m^3^)^a^; additional 0.3 and 0.5 ppm with peaks up to 1.0 ppm (1.23 mg/m^3^)^a^; additional 0.0, 0.3, and 0.5 ppm with ethyl acetate to “mask” formaldehyde.; Protocol: Exposure order randomly assigned; double blinded. Ten 4-hour exposure conditions, one per day, over 10 days. Airway resistance (R_tot_, PEF, FEV_1_, FEF_25-75_, and SGaw measured on first exam and on first and last exposure day, pre and post exposure. No exercise component. | No statistically different differences between baseline Day 1 and postexposure on Day 10 (data not presented).
Low Confidence (No randomization; blinding not discussed)
Reference: Day et al. (1984); Population: 2 groups of 9 adults each. Group 1, N = 9, adversely affected (nonrespiratory) by HCHO fumes emitted by urea foam insulation (UFFI) in their homes. Group 2, N = 9, not affected by UFFI present in their homes, or volunteer with no UFFI exposure. Descriptive data on study subjects was not presented.; Exposure: 1.5 hrs in chamber, 1.0 ppm (1.23 mg/m^3^)^a^, 0.5 hr under hood, 1.2 ppm (1.48 mg/m^3^)^a^; no clean air control.; Protocol: Testing before, after, and 6.5 hrs after exposure. No exercise component. | No change in FVC, FEV_1_, or FEF_25-75_ (mean ± SD) paired t-test
Reference: Sauder et al. (1986); Population: n = 9, mean age 26 ± 3.6 years, healthy, non allergic (for 6 wks prior to test), nonsmokers.; Exposure: 3 hrs; 0, 3 ppm (3.69 mg/m^3^)^a^; Protocol: Nonrandom assignment; blinding not described. 8-min bicycle exercise followed by spirometry measurements after each 30-min interval during 3 hr exposures. First day clean air only, second day 3 ppm formaldehyde. Testing again after 24 hrs. Repeated measures ANOVA | | Clean air | 3 ppm
| | 30 minutes
| FVC | 4.61 | 4.62
| FEV_1_ | 3.98 | 3.90*
| FEF_25-75_ | 4.46 | 4.16**
| | 180 minutes
| FVC | 4.71 | 4.68
| FEV_1_ | 4.02 | 3.99
| FEF25-75 | 4.45 | 4.48
| *p <0.05, ** p <0.01, paired t-test; Statistically significant decreases in FEV_1_ (2%) and FEF_25%-75%_ (7%) after first 30 minutes; Range in response:; FEV_1_ −5% to +1%; FEF_25-75_ −14% to +2%; No other changes during exposure or 24 hrs after.

a Concentrations reported by authors as ppm or ppb converted to mg/m^3^.

### C.5.2 Change in pulmonary function measures during a work shift or anatomy lab session

Daily changes in pulmonary function measures (e.g., across a work shift or during a lab session lasting a few hours) were assessed in studies among workers employed for several years in exposed jobs or among students enrolled in an anatomy lab. Declines in FEV_1_, FVC and FEV_1_/FVC were observed in some studies (Neghab et al., 2011; Horvath et al., 1988; Herbert et al., 1994; Alexandersson et al., 1982; Alexandersson and Hedenstierna, 1989) but not others (Malaka and Kodama, 1990; Löfstedt et al., 2009; Holness and Nethercott, 1989; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988). Most of the studies measured changes only among exposed individuals; measurements in a comparison group would have allowed adjustment for diurnal effects. Daily declines in FEF_25–75_ were more consistently reported by the occupational studies of wood products employees (Neghab et al., 2011; Malaka and Kodama, 1990; Horvath et al., 1988; Alexandersson et al., 1982), and exposed groups had larger decrements compared to the referent groups among the two studies that reported cross-shift changes in both groups (Malaka and Kodama, 1990; Horvath et al., 1988). One well-conducted study using repeated peak expiratory flow measures taken by students trained in the procedure at multiple points during dissection lab sessions found that PEF declined over the course of a lab and these daily declines became attenuated over successive weeks (Kriebel et al., 2001).

Figures C-19–C-21 present study findings for three spirometry measures, FEF_25-75_, FEV_1_, and FVC, and study details are summarized in Table C-25. For each measure, the mean difference across a work shift or lab session in exposed and referent groups (when reported) is plotted with error bars depicting the standard error. Separate graphs depict the mean before and after difference expressed as absolute value (e.g., FEV_1_ in liters) or percent predicted. The third plot shows results for studies that reported changes as a percent of the baseline value.

Figure C-19 Plots of change in FEF at 25–75% of FVC across a work shift or anatomy lab session by study with study details

The difference in reported means before and after shift or lab as either liters/second or % predicted are shown, and percent change in FEF across the lab was reported by two studies (3^rd^ panel). Mean difference or percent change and SE are shown. These were calculated by EPA when not reported using SD for before and after means.

Figure C-20 Plots of change in FEV1 across a work shift or anatomy lab session by study with study details

The difference in reported means before and after shift or lab as either liters or % predicted are shown, or percent change in FEV1 across the lab. Mean difference or percent change and SE are shown. These were calculated by EPA when not reported using SD for before and after means.

Figure C-21 Plots of change in FVC across a work shift or anatomy lab session by study with study details

The difference in reported means before and after shift or lab as either liters or % predicted are shown, or percent change in FVC across the lab. Mean difference or percent change and SE are shown. These were calculated by EPA when not reported using SD for before and after means.

Table C-25 Studies of pulmonary function measures during a work shift or anatomy lab session

Study information | Group characteristics | Measures reported and analysis methods
Occupational studies
(Neghab et al., 2011); Resin production; Confidence: Low (No comparison group) | Exposed: N = 70, male, age 38 year, 24% smokers; Referent: Not measured | FEV_1_, FVC, FEV_1_/FVC, PEF; Mean values (percent predicted) before and after shift compared (paired t-test) in exposed
(Löfstedt et al., 2009); Chemical company; Confidence: Medium (Healthy survivor effect) | Exposed: N = 64, 89% male, age 44 year, 25% smokers; Referent: N = 134, 88% male, age 40 year, 22% smokers | VC, FEV_1_; Compared mean difference across shift (percent predicted) between exposed and referent (regression); association with formaldehyde adjusting for isocyanate levels and smoking (regression)
(Malaka and Kodama, 1990); Plywood manufacture; Confidence: Medium (healthy survivors) | Exposed: N = 55, male, age 27 year, 53% smokers; Referent: matched by age, ethnicity, and smoking; N = 50, male, age 29 year, 53% smokers | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_; Mean values before and after shift compared (paired t-test) in exposed and referent
(Herbert et al., 1994); Particle board manufacture; Confidence: Low (No comparison group) | Exposed: N = 99, sex NR, age 35 year, 52% smokers; Referent: Not measured | FEV_1_, FVC, FEV_1_/FVC; Mean values before and after shift compared (paired t-test) in exposed
(Alexandersson and Hedenstierna, 1989) Cabinet manufacture, 5-year follow-up of (Alexandersson et al., 1982); Confidence: Low (No comparison group) | Exposed: N = 21, male, age 37 year, 48% smokers; Referent: Not measured | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_; Mean values before and after shift compared, stratified by smoking status (paired t-test) in exposed
(Holness and Nethercott, 1989); Funeral workers (embalming); Confidence: Medium (comparison groups selected from different source populations) | Exposed: N = 22, 89% male, age 32 year, 50% smokers; Referent (community volunteers): N = 13, 84% male, age 28 year, 37% smokers (Demographic information for are for entire study groups) | FEV_1_, FVC, FEF_50_, FEF_75_; Compared mean percent change during embalming (or after 2–3 hr) (percent predicted) between exposed and referent (regression adjusting for age, height, and pack-year smoked
(Horvath et al., 1988); Particle board manufacture; Confidence: High | Exposed: N = 109, 57% male, age 37 year, 53% smokers; Referent (food processing): N = 254, 44% male, age 34 year, 53% smokers | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_, PEF; Mean values before and after shift (percent predicted) compared (paired t-test) in exposed and referent; correlation with formaldehyde concentration
(Alexandersson and Hedenstierna, 1988); Alexandersson (1988); Wood products; Confidence: Low (No comparison group) | Exposed: N = 38, male, age 34 year, 50% smokers; Referent: Not measured | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_; Mean values before shift on first day and after shift on second day compared, stratified by smoking status (paired t-test) in exposed
(Alexandersson et al., 1982); Cabinet manufacture; Confidence: Low (No comparison group) | Exposed: N = 47, male, age 35 year, 51% smokers; Referent: Not measured | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_; Mean values before and after shift compared, stratified by smoking status (paired t-test) in exposed
Anatomy lab (dissection)
(Saowakon et al., 2015); Anatomy course; Confidence: Low (No comparison group) | N = 36, gender NR, age 19.8 year, nonsmokers; no referent | FVC, FEV_1_, FEV_1_/FVC, FEF_25-75_, PEF; Mean values compared before and after dissection session (paired t-test) in exposed
(Binawara et al., 2010); Anatomy course; Confidence: Low (No comparison group) | N = 80, male, age 20 year, nonsmokers; referent: No referent | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_, PEF; Mean values (percent predicted) before and after shift compared (paired t-test) in exposed
(Khaliq and Tripathi, 2009); Anatomy course; Confidence: Low (No comparison group; small sample size) | Exposed: N = 20, male, age 18 year, nonsmokers; no referent | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_, PEF; Mean values before and after lab compared (repeated measure ANOVA) in exposed
(Akbar-Khanzadeh and Mlynek, 1997) Anatomy course; Confidence: Low (Analyses did not account for possible acclimatization to formaldehyde over time) | Exposed: N = 50, 50% male, age 24 year, nonsmokers; referent (physiotherapy students): N = 36, 24% male, age 24 year, nonsmokers | FEV_1_, FVC, FEF_25-75_; Compared mean percent change (standardized for baseline) over lab in exposed and referent (paired t-test); compared difference between groups (unpaired t-test)
(Akbar-Khanzadeh et al., 1994); Anatomy course,; Confidence: Medium (Comparison groups dissimilar; small sample size in referent) | Exposed: N = 34, 71% male, age 26 year, nonsmokers; referent: N = 12, 67% male, age 31 year, nonsmokers | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_; Compared mean percent change (standardized for baseline) over lab in exposed and referent (paired t-test); compared difference between groups (unpaired t-test)
(Chia et al., 1992); Anatomy course; Confidence: Low (No comparison group; small sample size) | Exposed: N = 13 male, n = 9 female, age NR, smoking NR; referent: Not measured | FEV_1_, FVC (means adjusted for age and height); Mean values before and after lab compared (chisquare statistic)
(Uba et al., 1989); Anatomy course; Confidence: High | Exposed: N = 96, 74% male, age 24 year, nonsmokers; comparison: Cross-lab change week 2 vs. baseline day | FEV_1_, FVC, FEV_1_/FVC, FEF_25-75_; Mean percent change over lab session at 2 weeks compared to baseline (repeated measures ANOVA, adjusted for sex)

## C.6 RESPIRATORY TRACT PATHOLOGY (SUPPORTING INFORMATION FOR HAZARD)

### C.6.1 Short-term respiratory tract pathology studies in experimental animals

Due to the abundance of high-quality, longer duration exposure studies on respiratory tract effects in experimental animals, the results of supportive medium and high confidence short-term studies that did not provide information that was unexamined or inadequately examined in the longer term studies (i.e., species differences; the relative contribution of concentration and duration to lesion development) are summarized below in Table C-26 (note: the details of low confidence animal studies are not described for respiratory pathology owing to the large number of high and medium confidence studies available).

In addition, mechanistic evidence on changes in the respiratory tract, namely effects on mucociliary function and cellular proliferation, informed the interpretation of respiratory tract pathology. These effects are summarized in Appendix C.7.1.

Table C-26 Short-term respiratory pathology studies in animals

Reference and study design | Results
RAT
High Confidence
Reuzel et al. (1990); Wistar rats; male; 10/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 22 hrs/d for 3 d.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.37 (±0.01), 1.4 (±0.0), and 3.8 (±0.1) mg/m^3^.^1^; This study also evaluated the combined effects of ozone and FA mixtures on nasal epithelium. Data presented here in the Results column are for FA-only exposed rats.; Histopathologic evaluation of the respiratory tract included 6 standard sections of the nose.; Figure 1 from Reuzel et al. (1990) depicting cross levels of the rat nose evaluated for histopathological lesions.; Main limitations: No major limitations. | | | Concentration of FA
| | | 0 mg/m^3^ | | | 0.37 mg/m^3^ | | 1.4 mg/m^3^
| | | II^a^ | | III^a^ | II | III | II | III
| Disarrangement/loss of cilia without hyper/metaplasia
| Minimal to slight | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| Moderate | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| Disarrangement/loss of cilia with hyper/metaplasia
| Minimal to slight | | 0/10 | | 0/10 | 1/10 | 0/10 | 2/9 | 0/9
| Moderate | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| Marked | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| Keratinization
| Minimal to slight | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| Moderate | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| Rhinitis
| Minimal to slight | | 0/10 | | 0/10 | 2/10 | 0/10 | 1/9 | 0/9
| Moderate | | 0/10 | | 0/10 | 0/10 | 0/10 | 0/9 | 0/9
| ^a^Level in the nose examined.
| | | Concentration of FA
| | | 0 mg/m^3^ | | | 3.8 mg/m^3^
| | | II^a^ | III^a^ | | II | III
| Disarrangement/loss of cilia without hyper/metaplasia
| Minimal to slight | | 0/10 | 0/10 | | 0/10 | 0/10
| Moderate | | 0/10 | 0/10 | | 0/10 | 0/10
| Disarrangement/loss of cilia with hyper/metaplasia
| Minimal to slight | | 0/10 | 0/10 | | 7/10 | 3/10
| Moderate | | 0/10 | 0/10 | | 3/10 | 5/10
| Marked | | 0/10 | 0/10 | | 2/10 | 0/10
| Keratinization
| Minimal to slight | | 0/10 | 0/10 | | 7/10 | 0/10
| Moderate | | 0/10 | 0/10 | | 1/10 | 0/10
| Rhinitis
| Minimal to slight | | 0/10 | 0/10 | | 0/10 | 0/10
| Moderate | | 0/10 | 0/10 | | 0/10 | 0/10
| ^a^Level in the nose examined.; Histopathological changes for Level I not reported.; Histopathological changes for Levels IV, V, and VI reported together. Only change observed was minimal to slight rhinitis in rats (4/10) exposed to 3.8 mg/m^3^ FA.
Medium Confidence
Andersen et al. (2008); Fischer 344 rats; male; 8/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for up to 3 wks. Rats sacrificed at end of single 6-hr exposure (day 1), 18 hrs after single 6-hr exposure (day 1 recovery), at end of 5 d of exposure (day 5), at end of 6 d of exposure (day 6), 18 hrs after 6 d of exposure (day 6 recovery), and at end of 15 d of exposure (day 15).; Test article: Paraformaldehyde.; Actual concentrations were determined on a daily basis and reported in the Results column. Target concentrations were 0, 0.9, 2.5, 7.4, and 18.5 mg/m^3^.^1^; This study also evaluated the effects of a single FA instillation (40 μL, 400 mM per nostril). Data presented here in the Results column are for inhalation exposures.; Histopathologic evaluation of the respiratory tract included nasal sections at levels I (front of nose), II (anterior lateral meatus, anterior septum, medial aspect maxilloturbinate), and III (posterior lateral meatus, posterior septum).; Main limitations: small sample size; somewhat high variability in chamber concentrations. | Target and Actual FA Concentrations^a^
| Target concentration (mg/m^3^) | | Day 1 (mg/m^3^) | | Day 5 (mg/m^3^) | | Day 6 (mg/m^3^) | Day 15 (mg/m^3^)
| 0 | | 0±0 | | 0±0 | | 0±0 | 0±0
| 0.9 | | 0.74±0.23 | | 0.79±0.15 | | 0.75±0.16 | 0.7±0.11
| 2.5 | | 2.08±0.46 | | 2.14±0.43 | | 2.26±0.49 | 2.2±0.31
| 7.4 | | 5.83±1.73 | | 6.43±0.76 | | 6.00±1.25 | 6.14±0.97
| 18.5 | | 17.7±5.7 | | NA | | NA | NA
| ^a^Daily means ± SD.
| Histopathology Incidence
| | FA (mg/m^3^)
| | 0 | 0.9 | | 2.5 | | 7.4
| Time point | InI^a^ | InI | EH | InI | EH | InI | EH | SM
| Day 1 | 0^b^ | 1 | 0 | 6 | 0 | 8 | 0 | 0
| Day 1 R^c^ | 4 | 2 | 1 | 1 | 3 | 7 | 8 | 0
| Day 5 | 1 | 1 | 0 | 5 | 3 | 8 | 8 | 7
| Day 6 | 5 | 2 | 0 | 4 | 1 | 7 | 8 | 0
| Day 6 R | 6 | 1 | 0 | 3 | 2 | 7 | 8 | 0
| Day 15 | 3 | 1 | 0 | 0 | 2 | 5 | 7 | 0
| 0 ppm: EH and SM were ND; 0.7 ppm: SM was ND; 2 ppm SM was ND; ^a^InI = inflammatory infiltrate; EH = epithelial hyperplasia; SM = squamous metaplasia.; ^b^Number of animals with the lesion (n = 8).; ^c^Recovery group.
| Histopathological Incidence
| | FA (mg/m^3^)
| | 0 | 18.5
| | | Level I | | | Level II
| Time point | InI^a^ | InI | UcL | EH | InI | UcL | EH
| Day 1 | 0^b^ | 8 | NR | NR | 7 | 2 | 1
| 0 ppm: UcL was NR, EH was ND; ^a^InI = inflammatory infiltrate; UcL = ulcerative lesions; EH = epithelial hyperplasia.; ^b^Number of animals with the lesion (n = 8).
Cassee and Feron (1994); Wistar rats; male; 20/group.; Exposure: Rats were exposed in dynamic nose-only chambers for 3 d (6 consecutive 12-hr periods of 8 hrs of exposure to FA followed by 4 hrs of nonexposure). Rats sacrificed immediately (i.e., within 30 min) after last exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0 and 4.4 (SE ± 0.1) mg/m^3^ FA.; Histopathologic evaluation of the respiratory tract included standard cross sections of the head (see cross sections in Reuzel et al. (1990).; Main limitations: hyperplasia and metaplasia were reported together.; This study also evaluated the nasal changes induced by exposures to ozone alone and FA and ozone. Data presented here in the Results column are for FA-only exposures. | | | | Controls | | | FA
| Type of lesions | | | II^a^ | III^a^ | | II | III
| Disarrangement, flattening and slight basal cell hyperplasia
| Minimal | | | 0/5 | 1/5 | | 0/5 | 0/5
| Slight | | | 0/5 | 0/5 | | 0/5 | 0/5
| Frank necrosis | | | 0/5 | 0/5 | | 5/5 | 5/5
| Hyperplasia accompanied by squamous metaplasia
| Slight | | | 0/5 | 0/5 | | 2/5 | 3/5
| Moderate | | | 0/5 | 0/5 | | 2/5 | 2/5
| Marked | | | 0/5 | 0/5 | | 1/5 | 0/5
| Rhinitis
| Slight^b^ | | | 0/5 | 0/5 | | 0/5 | 0/5
| Moderate | | | 0/5 | 0/5 | | 0/5 | 4/5
| Marked | | | 0/5 | 0/5 | | 5/5 | 1/5
| ^a^Standard cross section level II and III.; ^b^Influx of neutrophils mainly observed.
Cassee et al. (1996b); Wistar rats; male; number of animals per group varied but are reported in the Results column.; Exposure: Rats were exposed to FA in dynamic nose-only chambers 6 hrs/d for 1 or 3 d. Rats sacrificed immediately after last exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0, 1.2, 3.9, and 7.9 mg/m^3^.^1^; Histopathologic evaluation of the respiratory tract included standard cross sections at levels II, III, and/or IV of the nose (see Reuzel et al. (1990) for cross-sectional levels).; Main limitations: small N; failure to report data for the 7.9 mg/m^3^ group.; This study also evaluated the combined effects of FA, acetaldehyde, and acrolein on nasal epithelium. Data presented here in the Results column are for FA-only exposed rats. | 1-day exposure: no treatment-related histopathological nasal lesions
| Histopathological changes from 3 days of exposure^a^
| | | | | | | FA (mg/m^3^)
| Site, type, degree, and incidence of lesions | | | | | | 0 | 1.2 | 3.9
| Number of noses examined | | | | | | 19 | 5 | 6
| Disarrangement, necrosis, thickening, and desquamation of respiratory/transitional epithelium^b^
| Slight (mainly disarrangement) | | | | | | 0 | 0 | 3
| Moderate | | | | | | 0 | 0 | 2
| Severe (extensive) | | | | | | 0 | 0 | 0
| Basal cell hyperplasia and/or increased number of mitotic figures in respiratory/transitional epithelium
| Slight (focal) | | | | | | 0 | 0 | 4
| Moderate | | | | | | 0 | 0 | 2
| Severe (extensive) | | | | | | 0 | 0 | 0
| Increased incidence of “single-cell necrosis” in olfactory epithelium^c^
| A few necrotic cells | | | | | | 0 | 0 | 0
| A moderate number of necrotic cells | | | | | | 0 | 0 | 0
| Many necrotic cells | | | | | | 0 | 0 | 0
| Atrophy of olfactory epithelium
| Slight (mainly disarrangement) | | | | | | 0 | 0 | 0
| Moderate (focal) | | | | | | 0 | 0 | 0
| Severe (extensive) | | | | | | 0 | 0 | 0
| Rhinitis
| Slight | | | | | | 2 | 1 | 0
| Moderate | | | | | | 1 | 0 | 0
| Severe | | | | | | 0 | 0 | 0
| ^a^Data for 7.9 mg/m^3^ group NR.; ^b^Changes observed at levels II and III.; ^c^Changes observed at levels III and IV.
Monteiro-Riviere and Popp (1986); Fischer 344 rats; male; 3–5/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d for either 1, 2, or 4 d. Interim sacrifices were performed either immediately or 18 hrs after last exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.6 (±0.1), 2.7 (±0.4), 7.3 (±0.1), and 18.2 (±0.4) mg/m^3^.^1^; Histopathologic evaluation of the respiratory tract included transverse sections of the skull that contained the dorsal nasal concha, lateral wall, and ventral nasal concha.; Main limitations: small N; (note: only 3 of 5 rats/treatment group were evaluated in “detail”); failed to report lesion incidence and severity | Cellular occurrence of ultrastructure lesion^a,b^ | | 7.3 mg/m^3c^ | | 7.3 mg/m^3^ (1-day)^d^ | | 7.3 mg/m^3^ (2-day) | | 7.3 mg/m^3^ (4-day)
| Cytoplasmic vacuoles | | ALL | | ALL | | | | NC
| Autophagic vacuoles | | BA | | BA | | | | BA, CU, NC
| Loss of microvilli | | CI | | CI | | CI | | CI, CU, BR
| Hypertrophy | | | | CI, GO | | CI, GO | | CI, GO
| SER in apical region | | | | NC | | | | NC
| Intracytoplasmic lumen | | | | | | CI
| Mitochondrial swelling | | | | | | | | CI, BR
| Neutrophils | | + | | + | | +
| Intercellular edema | | | | + | | +
| Ciliated mucous cells | | | | | | + | | +
| Nonkeratinized squamous cells | | | | | | | | +
| ^a^Abbreviations: BA, basal cells; CI, ciliated cells; CU, cuboidal cells; BR, brush cells; NC, nonciliated columnar cells; GO, goblet cells; SER, smooth endoplasmic reticulum; ALL, all cell types; +, indicates presence. Nucleolar segregation, pyknotic nuclei, and internalized cilia not observed.; ^b^These lesions were not observed at 0.6 mg/m^3^ (1 or 4 d exposure) or 2.7 mg/m^3^ (1 or 4 d exposure) FA.; ^c^Rats in this group were immediately sacrifice after exposure.; ^d^Number of days of exposure, rats sacrificed 18 hrs later.
| Cellular occurrence of ultrastructure lesion^a,b^ | | | 18.2 mg/m^3^ (1-d)^c^ | | | 18.2 mg/m^3^ (2-d)
| Cytoplasmic vacuoles | | | CU, NC | | | NC
| Autophagic vacuoles | | | BA, CI, CU, NC | | | BA, CU, NC
| Loss of microvilli | | | BA, CI, CU | | | CI, CU, NC
| SER in apical region | | | NC | | | NC
| Nucleolar segregation | | | BA, CU | | | BA, CU
| Pyknotic nuclei | | | CU | | | CI
| Internalized cilia | | | CI | | | CI
| Neutrophils | | | +
| Intercellular edema | | | +
| Nonkeratinized squamous cells | | | + | | | +
| ^a^Abbreviations: BA, basal cells; CI, ciliated cells; CU, cuboidal cells; BR, brush cells; NC, nonciliated columnar cells; GO, goblet cells; SER, smooth endoplasmic reticulum; ALL, all cell types; +, indicates presence. Hypertrophy, Intracytoplasmic lumen, mitochondrial swelling, and ciliated mucous cells not observed.; ^b^These lesions were not observed at 0.6 mg/m^3^ (1 or 4 d exposure) or 2.7 mg/m^3^ (1 or 4 d exposure) FA.; ^c^Number of days of exposure, rats sacrificed 18 hrs later.
Speit et al. (2011b); Fischer 344 rats; males; 6/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 4 wks.; Test article: Formalin (methanol concentration NR).; Actual concentrations were 0, 0.63 (±0.6), 1.23 (±0.14), 2.48 (±0.18), 7.53 (±0.42), 12.3 (±0.48), 18.4 (±0.06) mg/m^3^.^1^; Histopathologic evaluation of the respiratory tract included 4 levels of the nasal cavity: I (nasal septum, lateral meatus [wall], maxilloturbinate, nasoturbinate), II (nasal septum, lateral meatus [wall]), and III and IV (nasopharynx).; Main limitations: Formalin; small N | No FA-related histological changes observed in levels I–IV of rats exposed to 0.63, 1.23, 2.48, and 7.53 mg/m^3^.
| Histopathological analysis of nasal lesions after 4 wks
| | | | Incidence and grading of findings^a^
| | | | | FA (mg/m^3^)
| | | | Grade^b^ | 0 | 12.3 | 18.4
| Level I
| Metaplasia, squamous | | | 1 | 0 | 1 | 0
| | | | 2 | 0 | 5 | 0
| | | | 3 | 0 | 0 | 4
| | | | 4 | 0 | 0 | 2
| Degeneration, (multi) focal | | | 2 | 0 | 0 | 1
| | | | 3 | 0 | 0 | 3
| | | | 4 | 0 | 0 | 2
| Inflammation, (multi) focal | | | 2 | 0 | 0 | 1
| | | | 3 | 0 | 0 | 4
| Level II
| Metaplasia, squamous | | | 2 | 0 | 0 | 1
| | | | 3 | 0 | 0 | 5
| Degeneration, (multi) focal | | | 1 | 0 | 0 | 1
| | | | 2 | 0 | 0 | 2
| | | | 3 | 0 | 0 | 3
| Inflammation, (multi) focal | | | 2 | 0 | 0 | 1
| Level III
| Metaplasia, transitional | | | 1 | 0 | 0 | 4
| | | | 2 | 0 | 0 | 1
| Level IV
| Metaplasia, transitional | | | 1 | 0 | 0 | 2
| | | | 2 | 0 | 0 | 3
| ^a^Number of animal with lesions (6 analyzed per group).; ^b^1 = minimal; 2 = slight; 3 = moderate; 4 = severe/marked.

1 Study authors originally reported FA concentrations in ppm. These values were converted based on 1 ppm = 1.23 mg/m^3^, assuming 25°C and 760 mm Hg.

Abbreviations: FA—Formaldehyde; NA—Not applicable; ND—Not detected; NR—Not reported; SD—Standard deviation; SE—Standard error of the mean.

## C.7 MECHANISTIC EVIDENCE RELATED TO POTENTIAL NONCANCER RESPIRATORY HEALTH EFFECTS (SUPPORTING INFORMATION FOR HAZARD)

Note: Large sections of this analysis are redundant to synthesis text, figures, and tables presented in the Toxicological Review. However, the entirety of the analyses and discussion is included below to contextualize the conclusions described in the Toxicological Review with the appropriate methodological considerations, supporting analyses, and other information of potential interest.

This evaluation provides an integrated discussion characterizing potential relationships between the mechanistic changes observed following formaldehyde inhalation in the context of potential respiratory effects, but it does not attempt to explicitly define a single mode of action. The methods are described in Section 2 of the Toxicological Review. The identification of the studies is primarily documented in Appendix B.2.6, although some studies were identified through other health-effect specific searches (e.g., immune-mediated conditions; respiratory tract pathology) as described elsewhere. The evaluation of individual mechanistic studies is documented in Appendix B.3.6.

### C.7.1 Synthesis of Changes in the Upper Respiratory Tract (URT)

Data on formaldehyde-induced mechanistic changes in the URT are largely based on studies in experimental animals or acutely exposed human volunteers, as most of these endpoints are difficult to examine in long-term observational epidemiology studies. The specific studies and summary findings supporting the synthesis below are described in Table C-27. While the structure and function of the URT across species is considered similar, interpretation of compensatory or adaptive changes within the human URT following long-term exposure based on findings in experimental animals is difficult to infer.

The majority of the events which are potential initial or direct effects of formaldehyde (see asterisks in Figures C-23 and C-24) occur at the level of the respiratory epithelium, including evidence supporting the involvement of formaldehyde in reactions with cellular macromolecules such as proteins (e.g., detoxifying enzymes) and DNA, effects on the local redox system, and interactions with sensory nerve endings within the respiratory epithelium. While these events are interrelated, they could be caused by formaldehyde independently and simultaneously. Although some studies have reported changes in these initial mechanistic events at formaldehyde concentrations as low as 0.035 mg/m^3^ following acute or short-term exposure, notable uncertainties remain. For example, tissue alterations that might increase vulnerability to these changes with continued exposure is expected (e.g., decreases in mucociliary clearance). Conversely, gradual tissue changes following exposure might also lead to resilience (e.g., increases in epithelial cell barrier function). More detailed mechanistic studies characterizing the initial molecular interactions of formaldehyde in the URT following long-term exposure would help to clarify potential progressive changes in the ability of formaldehyde inhalation to elicit these initial changes.

Effects on the mucociliary system are likely secondary to the production of reactive byproducts or covalent modification to mucosal structural components following physical interactions of formaldehyde with proteins in the mucus. The effects of formaldehyde on mucus flow patterns appear to include both a concentration and exposure-duration dependency (as well as variability due to humidity), although a mechanism reliant on direct modification of macromolecules alone would be expected to be driven largely by concentration. The impact of this is difficult to define and integrate into the overall mechanistic picture. Persistent changes to the normally protective mucociliary apparatus or tissue redox capacity are likely to eventually lead to epithelial damage (which has been shown to correlate with inhibited mucociliary function following formaldehyde exposure). To repopulate damaged tissue and cells, and to protect against further insult, damage often leads to cell proliferation or hyperplasia (i.e., an increase in the amount of tissue due to proliferation of normal cells), and/or the damage can eventually lead to epithelial lesions such as squamous metaplasia, where cells transition to a different phenotype. This proliferation, hyperplasia, and/or metaplasia can be adaptive (e.g., response to tissue stress) or maladaptive, and could lead to subsequent effects on pulmonary function through thickening or keratinization of the respiratory epithelium, or thickening of mucus, all of which can restrict airflow. Formaldehyde exposure-induced damage to the URT epithelial cells could also result in an altered release of cytokines or other soluble mediators, which, were they to reach the LRT, could contribute to decreased pulmonary function through airway hyperreactivity and/or hypersensitivity to challenges such as allergen exposure (Hulsmann and Dejongste, 1996). In general, the plausible initial mechanistic events and changes in mucus flow patterns observed after formaldehyde exposure occur at lower formaldehyde levels than those eliciting URT epithelial lesions (i.e., at ≤0.3 mg/m^3^ in exposed humans and >0.6 mg/m^3^ in animals).

Inhaled formaldehyde also appears to directly stimulate trigeminal nerve endings in the nasal mucosa. Activation of these chemosensory afferents, likely C fibers, is known to initiate afferent signals that result in the burning sensation characteristic of sensory irritation. This chemosensory activation, which can also occur in the eyes, is enhanced in the anterior third of the nasal cavity and is typically less sensitive than olfaction (Hummel and Livermore, 2002). These characteristics are consistent with the known distribution of inhaled formaldehyde (see Appendix C.1) and with observations that formaldehyde exposure typically causes chemosensory-related irritation at higher concentrations than those necessary for olfactory detection in naïve individuals (e.g., as demonstrated by (Berglund et al., 2012)). The rapid detection of these sensations in exposed individuals suggests a receptor-mediated event that is dependent on formaldehyde penetration to the nerve endings, which may not have an exposure duration threshold. Based on mechanistic studies in vitro and ex vivo, activation of the trigeminal nerve by formaldehyde is likely mediated, at least in large part, through Transient Receptor Potential A1 (TRPA1) cation channels. To a lesser extent, this activation may also involve TRPV1 channels, which can be coexpressed and coactivated alongside TRPA1 in certain situations (Salas et al., 2009). Overall, very little is known about changes in chemosensitivity to inhaled formaldehyde with repeated exposure over time, as mechanistic studies of long-term exposure were not identified. With acute, controlled exposure in human volunteers, the initial irritation response to formaldehyde, which is highly variable across individuals, has been shown to plateau (e.g.,(Green et al., 1987)) or even decline somewhat (Bender et al., 1983) when exposure is continued for several minutes to hours; however, this pattern may depend upon concentration (Andersen and Molhave, 1983), and changes to this response pattern in humans over time, particularly with exposure longer than 1 day, remain unclear. Studies of reflex bradypnea in rodents (see Appendix C.2), which is dependent on the activation of the trigeminal nerve, show that repeated exposure for up to a month elicits a similar level of activation of this pathway. However, uncertainties with these data include a nonconstant exposure (i.e., short-term rodent studies employed work hour-like exposure periodicity) and testing only at reflex bradypnea-inducing levels (e.g., >1 mg/m^3^). It is unclear how this informs long-term responses to constant oronasal exposure in humans (who do not exhibit this reflex) at lower formaldehyde levels. Enhanced irritation with prolonged exposure could occur directly as a result of sensitization of the receptors (e.g., TRPA1) to formaldehyde or indirectly by increased access of formaldehyde to trigeminal nerve endings following damage to juxtaposed epithelial cells. Electrophilic oxidative stress products such as hydrogen peroxide and 4-hydroxynonenal are also known to be capable of stimulating sensory nerve receptors such as TRPA1 (Taylor-Clark et al., 2008; Alexandersson, 1988; Alexandersson and Hedenstierna, 1988), and moderate evidence exists to support the presence of oxidative stress in both the upper and lower airways. In addition, airway inflammation has been shown to reduce the threshold for activation of afferent fibers, through an unknown mechanism (Carr and Undem, 2001). Conversely, however, as this action is mediated predominantly by access of formaldehyde to chemoreceptors, changes such as the conversion of normal epithelium to squamous epithelium or damage and destruction of nerve afferents would be expected to reduce or desensitize subsequent irritant responses^15^. Taken together, this suggests a complex sequence of interactions that might impact trigeminal nerve chemosensation over time.

Together with the centrally mediated physiological response, stimulation of airway sensory nerves, including the trigeminal nerve, can also cause a more immediate localized release of neuropeptides like substance P and calcitonin gene-related protein (CGRP). These released neuropeptides, particularly substance P, can affect local immune responses by increasing vascular permeability and leukocyte recruitment, among other things (Sarin et al., 2006), as has been demonstrated with substance P-dependent eosinophil accumulation in the human nasal mucosa after allergen exposure (Fajac et al., 1995). Observations of neuropeptide changes, including increased substance P, have been reported at slightly higher formaldehyde levels than those shown to activate the trigeminal nerve, generally >1 mg/m^3^. While URT neuropeptide levels have not been examined in great detail following formaldehyde exposure, given that the URT represents the primary region of formaldehyde flux, formaldehyde exposure-induced increases in neuropeptides in model systems and related tissue regions, including the LRT, are inferred to provide support for the few URT-specific studies that observed elevated neuropeptide levels. The formaldehyde-specific data further indicate that the neuropeptides are released from neuronal rather than nonneuronal sources, at least following short-term exposure, and this release appears to be at least partially dependent on TRPA1 activation. The formaldehyde-specific URT studies have not examined many of the potential consequences of these changes, particularly after long-term exposure. Elevated URT neuropeptides might result in local inflammatory changes ranging from increased histamine and mucus secretion to edema and nasal obstruction during normal or exaggerated attempts to minimize nasal irritation (Barnes et al., 1991a, b).

The immune response in the URT following formaldehyde exposure has not been thoroughly studied, particularly in exposed humans; however, the available evidence does provide moderate support for granulocyte (e.g., eosinophils; neutrophils) involvement. The available data generally indicate that eosinophils are increased in the URT with acute or short-term exposure at ≈0.5 mg/m^3^, although one study suggests the possible increases at much lower levels in exposed humans with longer exposure (Norback et al., 2000). Although the role for eosinophils in the upper airways of exposed individuals remains unclear, airway eosinophils are known to be tightly regulated and uncommon in normal airways. In addition to their traditional role as immune “effectors” (i.e., releasing toxic molecules to destroy invading pathogens), activation of eosinophils can also cause them to release a number of chemical mediators which damage epithelial cells, stimulate mucus secretion, induce airway hyperresponsiveness, and perpetuate further recruitment of inflammatory mediators into the airway (Cohn et al., 2004). Eosinophils, which are relatively rare (≈1%) blood leukocytes, are a hallmark of allergic asthma (Howarth et al., 2000); however, no formaldehyde-specific studies meeting the inclusion criteria evaluated the URT for changes in other commonly observed inflammatory markers of allergic individuals such as activated mast cells or histamine. In addition, the data are unable to inform whether this inflammatory change persists in the human URT with long-term exposure. It should be recognized that acute inflammation is a protective response of the tissue to stress or damage; inflammation is more concerning when it becomes dysregulated, recurrent, and/or persistent.

At much higher concentrations (>5 mg/m^3^), neutrophils also appear to increase within the upper airways, presumably via migration from the blood. Neutrophils, which are the most common (≥50%) blood leukocyte, are also relatively uncommon (≤2%) in healthy airways. These phagocytic cells, along with eosinophils, are one of the first cells recruited to inflamed tissues shortly after infection. Both eosinophils and neutrophils can release toxic mediators, including lipid-active factors and reactive oxygen species (ROS), for which moderate evidence exists to support increased levels in the URT following formaldehyde exposure, and can damage bystander epithelial cells. However, in contrast to eosinophils, neutrophils are not thought to be associated with allergic responses or asthma, although they can be increased in individuals with pulmonary disease (O’Donnell et al., 2006). Changes in other cells in the URT, including basophils, macrophages, and lymphocytes, were not observed in the few short-term studies examining them.

Exactly how or why eosinophils and neutrophils migrate to the upper airways following formaldehyde exposure remains unclear. One possibility is that this response is related to the slight evidence of increased frequency and duration of URT infections in chronically exposed humans. However, while this effect might be caused by loss of barrier function (e.g., from epithelial cell damage or inhibited mucociliary function) leading to increased colonization of the epithelium by bacteria, this is not temporally plausible for the eosinophil increases observed following acute exposure. Evidence of specific changes in chemoattractants known to stimulate recruitment of these cells to the URT (e.g., eotaxin; IL-5; or, indirectly, TNFα or IL-1β, which can stimulate eotaxin in epithelial cells) was not identified, and thus, the biological explanation for the recruitment of these cells to the upper airways is unknown. Although not examined, it is also possible that formaldehyde could directly or indirectly (e.g., through tissue damage) interact with and modify epithelial components, including pattern recognition receptors, that can trigger release of ROS and lead to immunological responses (Lambrecht and Hammad, 2012; Kim et al., 2015a). Overall, although moderate evidence indicates that inflammatory cells including eosinophils and neutrophils are increased in the URT following formaldehyde exposure, the data are limited in their ability to define the concentration and duration requirements for the effects of formaldehyde exposure on URT immunological processes, which might inform how these changes are initiated.

Table C-27 Summary of changes in the upper respiratory tract (URT) resulting from formaldehyde exposure

Endpoint | Study-specific findings from “high or medium” or “low” confidence experiments | | Summary of evidence ([underlined: exposure duration]) | Conclusion
Structural Modification of the Upper Airways
Modification of biological macromolecules [see Appendix C.1 and C.3 for additional detail] | High or Medium | Human: None (note: binding of formaldehyde to albumin and other soluble proteins in human mucus has been demonstrated in vitro; e.g., Bogdanffy et al. (1987); hemoglobin adducts at ≈0.2 mg/m^3^, Bono et al. (2012) | Consistent with its known chemistry, formaldehyde can modify cellular biological macromolecules, including DNA, and interacts with soluble factors such as albumin and glutathione, shortly after exposure to low concentrations (e.g., <0.5 mg/m^3^) across a [underlined: wide range of exposure durations] | Robust
Modification of biological macromolecules [see Appendix C.1 and C.3 for additional detail] | High or Medium | Animal: Multiple animal studies demonstrate that inhaled formaldehyde can bind and modify biological macromolecules, which is consistent with the known biological reactivity of formaldehyde; evidence includes increased DNA-protein crosslinks (DPXs), hydroxymethyl (hm) DNA adducts, and reactions with glutathione; (e.g., increased DPXs are observed at ≥0.37 mg/m^3^, Casanova et al. (1989); hmDNA adducts and protein adducts at ≥0.86 mg/m^3^, (Lu et al., 2010a; Lu et al., 2011; Edrissi et al., 2013b) | | Robust
Modification of biological macromolecules [see Appendix C.1 and C.3 for additional detail] | Low | Human: N/A (see summary) | Sufficient information for ‘Robust’ from high or medium confidence studies | Robust
Modification of biological macromolecules [see Appendix C.1 and C.3 for additional detail] | Low | Animal: N/A (see summary) | Sufficient information for ‘Robust’ from high or medium confidence studies | Robust
Impaired Mucociliary Function | High or Medium | Human: decreased mucus flow at ≥0.3 mg/m^3^ after acute exposure and pathological changes in mucociliary clearance in workers at mean exposed levels of 0.25–0.26 mg/m^3^ after chronic exposure (Holmström and Wilhelmsson, 1988; Andersen and Molhave, 1983). | Decreased mucus flow and ciliary beat, and impaired clearance, in humans and rats at ≥0.25 and ≥2.5 mg/m^3^, respectively (observed [underlined: across exposure durations]), eventually leading to cilia loss | >Robust
Impaired Mucociliary Function | High or Medium | Animal: mucociliary function was generally unaffected at 0.57 mg/m^3^ after short-term exposure―minor changes were notable at 2.46 mg/m^3^; robust changes were observed at the next highest concentrations tested, ≥7.27 mg/m^3^; a general lack of recovery with longer exposure duration | | >Robust
Impaired Mucociliary Function | Low | Human: Increases in ciliary activity at 1.23 mg/m^3^ in dissociated human nasal epithelial cells (Wang et al., 2014b), with decreased cilia beating frequency in human epithelial cells at ≥3.46 mg/m^3^ (Wang et al., 2014b; Schafer et al., 1999): in vitro acute | Suggestive of decreased ciliary beat and ciliastasis at ≥5 mg/m^3^ in humans and rats with [underlined: acute] exposure, and cilia damage at ≥0.5 mg/m^3^ with [underlined: short-term] exposure; usually preceded by initial effects including slight increases in activity | >Robust
Impaired Mucociliary Function | Low | Animal: Ciliastasis and mucostasis: (Morgan et al., 1986a; Morgan et al., 1986c) acute 14.76 mg/m^3^ (not ≤2.46 mg/m^3^; recovery); Morgan et al. (1984): acute in vitro (frog palates) ≥5.36 mg/m^3^ (authors noted early activity increase, even at 1.69 mg/m^3^); structural cilia changes: (Monteiro-Riviere and Popp, 1986) short-term ≥0.5 mg/m^3^, (Abreu et al., 2016) acute at 0.25, but not 1.2–3.7 mg/m^3^ | | >Robust
Structural Change in URT Mucus Membrane or Nasal Obstruction | High or Medium | Human: Membrane hypertrophy, atrophy, rhinitis: (Lyapina et al., 2004) chronic (years) 0.87 mg/m^3^ | Mucus membrane damage and swelling in humans at 0.87 mg/m^3^ with [underlined: chronic] exposure | Moderate particularly in persons with nasal damage
Structural Change in URT Mucus Membrane or Nasal Obstruction | High or Medium | Animal: None | Mucus membrane damage and swelling in humans at 0.87 mg/m^3^ with [underlined: chronic] exposure | Moderate particularly in persons with nasal damage
Structural Change in URT Mucus Membrane or Nasal Obstruction | Low | Human: Data suggest increased mucosal swelling, nasal obstruction, and/or rhinitis in workers (Holmström and Wilhelmsson, 1988) chronic at 0.26 mg/m^3^ and (Norback et al., 2000): short-term at ≤0.016 mg/m^3^, which did not increase in severity with longer exposure; increase in mucosal swelling in symptomatic nasal distress patients, but not healthy controls: Falk et al. (1994) acute (2 hr) ≥0.073 mg/m^3^ | Observations at ≤0.26 mg/m^3^ in humans or at >3.5 mg/m^3^ in rats support data from the chronicduration study and suggest increased acute vulnerability of people with a prior nasal condition | Moderate particularly in persons with nasal damage
Structural Change in URT Mucus Membrane or Nasal Obstruction | Low | Animal: Rhinitis and necrosis in rats after acute or short term (1–3 d) at ≥3.94 or 4.43 mg/m^3^ | Observations at ≤0.26 mg/m^3^ in humans or at >3.5 mg/m^3^ in rats support data from the chronicduration study and suggest increased acute vulnerability of people with a prior nasal condition | Moderate particularly in persons with nasal damage
URT Epithelial Damage or Dysfunction [see Toxicological Review Section 3.2.4 for additional data and discussion] | High or Medium | Human: Indirect data indicating epithelial damage, including loss of ciliated cells, in occupational studies at 0.1–>2 mg/m^3^ (Holmström and Wilhelmsson, 1988), 1989, 3564; Edling et al. 1987, 4059 (Edling et al., 1988; Ballarin et al., 1992), with one with more equivocal findings (Boysen et al., 1990); however, these histopathological symptom scores included hyperplasia and metaplasia, which complicate interpretation | [underlined: Duration-dependent] epithelial damage, typically at ≥2.5 mg/m^3^ in [underlined: subchronic or chronic] rat studies, and with supportive indirect findings from human studies at 0.1–0.2 mg/m^3^, generally correlates with inhibited mucociliary activity | Robust
URT Epithelial Damage or Dysfunction [see Toxicological Review Section 3.2.4 for additional data and discussion] | High or Medium | Animal: Increased epithelial damage and related nasal lesions: duration-dependent, typically ≥2.46 mg/m^3^ in subchronic and chronic studies (e.g., (Andersen et al., 2010))lower in some longer-term studies) and generally correlating with inhibited mucociliary activity; goblet cell loss in monkeys (Monticello et al., 1989) short term (1 wk) at 7.38 mg/m^3^ | | Robust
URT Epithelial Damage or Dysfunction [see Toxicological Review Section 3.2.4 for additional data and discussion] | Low | Human: None | Studies suggest that nasal epithelial damage is increased, even in [underlined: short-term] studies, at ≥2.5 mg/m^3^ | Robust
URT Epithelial Damage or Dysfunction [see Toxicological Review Section 3.2.4 for additional data and discussion] | Low | Animal: Goblet cell damage and decreased junctional proteins between epithelial cells in rats (Arican et al., 2009): subchronic (12 weeks) at 18.5 mg/m^3^; mRNA and/or miRNA changes associated with apoptosis (Rager et al., 2014): short term (2 d in macques or 28 d in rats) or DNA repair (Andersen et al., 2010): short term (1 wk, but not at 4–13 week durations) at ≥2.46 mg/m^3^; Rhinitis and necrosis in rats after acute or short term (1–3 d) at ≥3.94 or 4.43 mg/m^3^ | Studies suggest that nasal epithelial damage is increased, even in [underlined: short-term] studies, at ≥2.5 mg/m^3^ | Robust
URT Cellular (Epithelial) Proliferation [see Toxicological Review Section 3.2.4 for additional data and discussion] | High or Medium | Human: None: indirect data from humans indicating an increase in histopathological scores that sometimes included hyperplasia were not specific enough to independently evaluate proliferation | Increased cell proliferation in rats at [underlined: all tested durations]. Proliferation increases were typically observed in the anterior nasal cavity at tested levels ≥≈3.5–4 mg/m^3^, and were generally not observed at ≤1.23 mg/m^3^. Sites of proliferation correlated with the development of hyperplasia and metaplasia, although the temporal and exposure levels specifics of this association are unclear. Indirect data from observations of hyperplasia in exposed animals and humans are consistent with these data. | >Robust ↑
URT Cellular (Epithelial) Proliferation [see Toxicological Review Section 3.2.4 for additional data and discussion] | High or Medium | Animal: Acute dose-dependent increases in cell proliferation in rats, measured primarily by DNA labeling during the final days of exposure, were consistently observed following acute, short-term, and subchronic exposure, and generally with a similar magnitude of responses across durations. Proliferation was typically highest in anterior regions (e.g., “level 2”), with little evidence of proliferation at ≤1.23 mg/m^3^, mixed findings between 1.24 and 3.5 mg/m^3^, and studies generally reporting increases with exposure at higher levels, particularly with longer exposure duration. These data are supported by consistent observations of formaldehyde exposure-induced increases in hyperplasia in pathology studies, some of which provided information showing a correlation between acute proliferation and hyperplasia and metaplasia. The only rat study that measured exposure longer than 13 wks suggests that increases in acute proliferation may begin to decrease in magnitude with chronic exposure at ≥6 mg/m^3^ (Monticello et al., 1996). A few studies suggest that mice may exhibit less robust responses than rats, while monkeys may exhibit proliferation in more posterior nasal regions at >7 mg/m^3^. | | >Robust ↑
URT Cellular (Epithelial) Proliferation [see Toxicological Review Section 3.2.4 for additional data and discussion] | Low | Human: N/A (see summary) | Sufficient information for ‘Robust’ from high or medium confidence studies | >Robust ↑
URT Cellular (Epithelial) Proliferation [see Toxicological Review Section 3.2.4 for additional data and discussion] | Low | Animal: N/A (see summary) | Sufficient information for ‘Robust’ from high or medium confidence studies | >Robust ↑
Sensory Nerve-Related Changes
Trigeminal Nerve Stimulation | High or Medium | Human: None | Increased activity of trigeminal nerve afferents at <0.5 mg/m^3^ following [underlined: acute] exposure in animals | Robust ↑
Trigeminal Nerve Stimulation | High or Medium | Animal: Increased afferent nerve activity: Tsubone and Kawata (1991) acute ≈20% at 0.62 mg/m^3^ and ≈50% at 2.21 mg/m^3^; Kulle and Cooper (1975) acute (threshold detection at 25 sec) at 0.31 mg/m^3^ | Increased activity of trigeminal nerve afferents at <0.5 mg/m^3^ following [underlined: acute] exposure in animals | Robust ↑
Trigeminal Nerve Stimulation | Low | Human: None | Supportive indirect evidence from ex vivo and in vitro experiments | Robust ↑
Trigeminal Nerve Stimulation | Low | Animal: Indirect evidence: with acute exposure, dose-dependent increase in nerve currents and Cl―release in intact rat trachea (Luo et al., 2013), and stimulation using in vitro neuronal preparations (Mcnamara et al., 2007; Kunkler et al., 2011) | Supportive indirect evidence from ex vivo and in vitro experiments | Robust ↑
TRPA1 and/or TRPV1 Stimulation | Low | Human: None | Indirect data identify TRPA1 as a molecular target for formaldehyde exposure-induced sensory effects | Moderate (TRPA1); Slight (TRPV1: not shown in Figures C-23 and C-24)
TRPA1 and/or TRPV1 Stimulation | Low | Animal: Formaldehyde and related chemicals such as acrolein activate the trigeminal system in wild-type mice, but not TRPA1 knockout mice following acute exposure, at least at high exposure levels (Yonemitsu et al., 2013); taken together with the established role for TRPA1 in acrolein-induced sensory effects (e.g., (Bautista et al., 2006)); these data indirectly support a role for TRPA1 in sensory nerve-related changes following formaldehyde exposure | Indirect data identify TRPA1 as a molecular target for formaldehyde exposure-induced sensory effects | Moderate (TRPA1); Slight (TRPV1: not shown in Figures C-23 and C-24)
TRPA1 and/or TRPV1 Stimulation | Low | Human: None | Indirect data identify TRPA1 and/or TRPV1, as molecular target(s) of formaldehyde exposure with [underlined: acute or short-term] exposure; inhibitor studies demonstrate that downstream effects of sensory nerve stimulation depend on TRPA1 or TRPV1 stimulation. | Moderate (TRPA1); Slight (TRPV1: not shown in Figures C-23 and C-24)
TRPA1 and/or TRPV1 Stimulation | Low | Animal: Formaldehyde activates the transient receptor potential cation channels, TRPA1 and TRPV1, in in vitro and ex vivo models relevant to acute inhalation exposure of the URT and upper LRT: (Mcnamara et al., 2007; Luo et al., 2013), and in vivo using formalin as a pain stimulus (not shown); Inhibition of TRPA1 and TRPV1 channels localized to sensory nerve endings reduce FA exposure-induced nerve currents in rat trachea (Luo et al., 2013) and immune-related responses in mice (Wu et al., 2013; Lu et al., 2005): 1 or 3 mg/m^3^ for 2 or 4 wk | | Moderate (TRPA1); Slight (TRPV1: not shown in Figures C-23 and C-24)
Neuropeptide Release | High or Medium | Human: None | Indirect evidence that Substance P was increased with [underlined: subchronic] exposure in a single mouse study at 2.46 mg/m^3^ | Moderate ↑ (relevant to both URT and LRT; note: evidence for NK Receptor involvement is Slight)
Neuropeptide Release | High or Medium | Animal: in plasma: Increased substance P in mice with subchronic exposure (Fujimaki et al., 2004b): subchronic at 2.46 mg/m^3^ | Indirect evidence that Substance P was increased with [underlined: subchronic] exposure in a single mouse study at 2.46 mg/m^3^ | Moderate ↑ (relevant to both URT and LRT; note: evidence for NK Receptor involvement is Slight)
Neuropeptide Release | Low | Human: in URT: Substance P in nasal lavage is increased in human volunteers with ocular exposure (He et al., 2005): 4 d (5 min/d) at 3 mg/m^3^, but not at 1 mg/m^3^ | Data suggest formaldehyde activates TRP channels on sensory neurons, leading to release of CGRP and substance P, with [underlined: acute] or [underlined: short-term] exposure at >1 mg/m^3^ | Moderate ↑ (relevant to both URT and LRT; note: evidence for NK Receptor involvement is Slight)
Neuropeptide Release | Low | Animal: in URT: Formaldehyde stimulates release of calcitonin gene related-protein (CGRP) in in vitro models relevant to inhalation exposure of the URT (Kunkler et al., 2011); Experiments using the related chemical, acrolein, suggest this is TRPA1-mediated (Kunkler et al., 2011).; in LRT: Inhibition of substance P receptor (NK1) inhibited formaldehyde-induced currents in isolated rat trachea (Luo et al., 2013); increased substance P and CGRP in mouse BAL, both amplified with ovalbumin (OVA) sensitization, and both involved TRP activation (Wu et al., 2013): short term at 3 mg/m^3^ | Data suggest formaldehyde activates TRP channels on sensory neurons, leading to release of CGRP and substance P, with [underlined: acute] or [underlined: short-term] exposure at >1 mg/m^3^ | Moderate ↑ (relevant to both URT and LRT; note: evidence for NK Receptor involvement is Slight)
Immune and Inflammation-Related Changes
URT Oxidative Stress | High or | Human: Increased nasal epithelial M1dG adducts (marker for oxidative stress and lipid peroxidation (Bono et al., 2016): unknown duration (but likely years) at >0.066 mg/m^3^ Animal: mRNA changes indicating increased stress-response proteins: (Andersen et al., 2008) short-term ≥2.46 mg/m^3^ | Direct and indirect evidence of elevated reactive oxygen species (ROS), possibly at very low concentrations (e.g., at >0.066 mg/m^3^, with a maximum of 0.444 mg/m^3^) with [underlined: prolonged] human exposure | Moderate ↑
URT Oxidative Stress | Low | Human: Increased nasal lavage nitrites (Priha et al., 2004): acute (8 hr shift) 0.19 mg/m^3^ | Data suggest elevated oxidative stress at very low formaldehyde concentrations with [underlined: acute] and [underlined: short-term] exposure. | Moderate ↑
URT Oxidative Stress | Low | Animal: Increased glutathione peroxidase and/or nonprotein sulfhydryl groups (Cassee et al., 1996b) and (Cassee and Feron, 1994): short-term (3 d) 3.94 and 4.43 mg/m^3^, respectively | Data suggest elevated oxidative stress at very low formaldehyde concentrations with [underlined: acute] and [underlined: short-term] exposure. | Moderate ↑
Nasal Cellular Inflammatory Response | High or Medium | Human: None | Cellular infiltration observed by histology, primarily neutrophils, but indirectly supporting other immune cell infiltration, in [underlined: short-term] animal studies at 7.38 mg/m^3^. Indirect evidence of increases in granulocytes (and possibly lymphocytes) at 2.46 mg/m^3^ with short term exposure. | Moderate ↑ granulocytes (neutrophils, eosinophils); Note: data on lymphocytes considered Indeterminate
Nasal Cellular Inflammatory Response | High or Medium | Animal: Increased inflammatory response, mostly neutrophils but also mention of lymphocytes and other inflammatory cells (e.g., assumed monocytes, basophils and eosinophils): (Monticello et al., 1989) short-term (1 or 6 wk) 7.38 mg/m^3^; “inflammatory cell” infiltration: (Andersen et al., 2008) acute or short-term (1 d–3 wk) 7.38 mg/m^3^; mRNA and miRNA changes associated with inflammation in rats and nonhuman primates: (Rager et al., 2013; Rager et al., 2014) short-term (1 or 4 wk, with some miRNA changes reversible with 1 wk recovery) at 2.46 mg/m^3^: 35 formaldehyde-responsive transcripts altered in the nose known to be related to immune cells indirectly indicated increases in granulocytes (i.e., eosinophil and neutrophil markers) and lymphocyte changes, and (Andersen et al., 2010): short-term (1 wk, but not ≥4 wk) at ≥12.3 mg/m^3^ | | Moderate ↑ granulocytes (neutrophils, eosinophils); Note: data on lymphocytes considered Indeterminate
Nasal Cellular Inflammatory Response | Low | Human: N/C in nasal lavage cell counts, but increased total protein: Priha et al. (2004) occupationally exposed (8-hr shift) 0.19 mg/m^3^; Allergy-independent increased eosinophils, permeability (albumin index) and total protein in lavage: Pazdrak et al. (1993) acute (2 hr) 0.5 mg/m^3^; increased eosinophils, leukocytes, and permeability (albumin index) in lavage: (Krakowiak et al., 1998) acute (2 hr) 0.5 mg/m^3^ (reversible); indirect evidence of eosinophil infiltration (increased markers: lysozyme and eosinophil cationic protein), but not neutrophils, at very low levels (Norback et al., 2000): <0.02 mg/m^3^; unknown duration (likely months or more) in schools | Suggestive of cellular inflammation, particularly eosinophils, at 0.5 mg/m^3^ and indirect markers of eosinophil recruitment at lower levels in humans, following [underlined: acute] exposure; neutrophil inflammation observed at ≥6 mg/m^3^ in rats with [underlined: short-term] exposure | Moderate ↑ granulocytes (neutrophils, eosinophils); Note: data on lymphocytes considered Indeterminate
Nasal Cellular Inflammatory Response | Low | Animal: Neutrophil inflammation: (Monteiro-Riviere and Popp, 1986) short-term ≥6 mg/m^3^ | | Moderate ↑ granulocytes (neutrophils, eosinophils); Note: data on lymphocytes considered Indeterminate
Altered URT Immunity (inferred from URT infections) | High or | Human: Increased frequency and duration of URT infections in symptomatic workers; increased chronic URT inflammation (and decreased function of blood neutrophils, but N/C in leukocyte counts) in exposed workers (Lyapina et al., 2004): chronic (years) 0.87 mg/m^3^ [Note: recent URT infection was often an exclusion criterion in observational studies focusing on pulmonary function; see Section A.5.3) | Indirect evidence of decreased immune capacity in a single study of [underlined: chronic] human exposure at 0.87 mg/m^3^ (note: while altered immunity was observed in an mRNA study, these changes were not necessarily indicative of decreased immune response) | Slight ↑URT infection
Altered URT Immunity (inferred from URT infections) | High or | Animal: mRNA changes suggestive of altered immune response (Andersen et al., 2010): ≥12.3 mg/m^3^ short-term (≥1 wk) | | Slight ↑URT infection
Altered URT Immunity (inferred from URT infections) | Low | Human: None | No evidence to evaluate | Slight ↑URT infection
Altered URT Immunity (inferred from URT infections) | Low | Animal: None | No evidence to evaluate | Slight ↑URT infection

#### Synthesis on Mucociliary Function in the Respiratory Tract

Mucociliary function studies in animals, which primarily focused on quantifying mucus flow rate and qualitative descriptions of ciliary beat frequency and viscosity, were limited to a set of studies from one research group examining dissected nasal passages. Studies of exposed humans were similarly limited, with relevant endpoints being evaluated in a prevalence study and an acute, controlled exposure study. Data are sparse, but in general, mucus flow and/or ciliary beat were inhibited by formaldehyde exposure as a function of concentration and, at least in rats, exposure duration. Effects were most pronounced in the anterior nasal regions, with effects progressing towards posterior regions after extended exposure durations in rats (see Tables C-28 to C-29). These functional observations are consistent with histological changes observed in experimental animals, including decreased cilia content in rhesus monkeys after 1 or 6 weeks of exposure to 7.38 mg/m^3^ (Monticello et al., 1989) and blebbing of ciliary membranes at formaldehyde concentrations as low as 0.62 mg/m^3^, with more overt signs of damage at ≥7.38 mg/m^3^, in rats exposed for 1 or 4 days (Monteiro-Riviere and Popp, 1986).

In well-conducted experiments in F344 rats, mucociliary function was generally unaffected after exposure to 0.57 mg/m^3^ formaldehyde for <1 to 14 days (Morgan et al., 1986a; Morgan et al., 1986c). Although sporadic, minor changes were notable at 2.46 mg/m^3^, including slight increases in mucus flow rate, inhibition of ciliary beat and mucus flow became clearly apparent at the next highest concentrations tested, ≥7.27 mg/m^3^. Initial increases in mucociliary activity at somewhat lower level formaldehyde concentrations were also apparent immediately after in vitro exposure, including increases in ciliary activity at 1.49 mg/m^3^ in ex vivo frog palates and at 1.0 mg/m^3^ in dissociated human nasal epithelial cells (Wang et al., 2014b; Morgan et al., 1984), with observations of mucostasis and ciliastasis at ≥5.36 mg/m^3^ in frog palates and decreased cilia beating frequency in human epithelial cells at ≥3.46 mg/m^3^ (Wang et al., 2014b; Schafer et al., 1999; Morgan et al., 1984); however, these in vitro studies are interpreted with low confidence. Two studies in humans reported consistent effects, with decreased mucus flow at ≥0.3 mg/m^3^ after exposure for several hours, and pathological changes in mucociliary clearance in workers exposed to mean formaldehyde levels of 0.25–0.26 mg/m^3^ for several years (Holmström and Wilhelmsson, 1988; Andersen and Molhave, 1983).

In rats, impaired function was most frequent in the dorsal and medial maxilloturbinate, the lateral wall, and portions of the nasoturbinate (Morgan et al., 1986a; Morgan et al., 1986c). This is consistent with the locations of epithelial lesions, which correlate with areas of inhibited ciliary function (Morgan et al., 1986c). Similarly, mucus flow was inhibited in the anterior nose of exposed human volunteers (Andersen and Molhave, 1983). However, whereas mucociliary function was affected with increasing severity with increasing exposure duration over several days in rats (Morgan et al., 1986c), effects on mucus flow rate did not vary with exposure durations of up to several hours in human volunteers (Andersen and Molhave, 1983). Seemingly consistent with this finding, mucociliary function in rat nasal passages was reported to recover considerably within 1 hour after 90 minutes of exposure to 18.5 mg/m^3^ (Morgan et al., 1986a); however, less recovery occurred after exposure for 6 hours (Morgan et al., 1986a), and little or no recovery was observable 18 hours after exposure for multiple days at similar concentrations (Morgan et al., 1986c). These data suggest that the initial changes observed in response to exposure may vary somewhat from the functional changes induced by sustained formaldehyde exposure.

Overall, mucociliary function is affected in a concentration-dependent manner shortly after formaldehyde inhalation, and this impaired function can be persistent, at least when exposure exceeds several hours, as indicated by studies in F344 rats and exposed workers. In rats, impaired function worsens with increasing exposure duration, although durations longer than 2 weeks have not been tested.

Table C-28 Mucociliary function studies in experimental animals

Reference and study design | Results
Rats
High confidence
Morgan et al. (1986a); Fischer 344 rats; male; 3–8/exposed groups and 9/control group.; Exposure: Rats were exposed to FA in dynamic head-only chambers for 10, 20, 45, or 90 min or 6 hrs with or without a 1-hr recovery period.; Test article: Paraformaldehyde.; Actual concentrations were within 5% of nominal concentrations of 0, 2.5, or 18.5 mg/m3.^a^; Mucociliary function (i.e., mucus flow pattern, mucus flow rate, and ciliary activity) evaluated by using dissected nasal mucosa that included the nasal septum and lateral wall.; Figure 2 from Morgan et al. (1986b) depicting areas of rat nasal passages used to determine flow rate on nasal septum and lateral wall.; Main limitations: No major limitations | Changes in mucociliary function
| Group | Observations
| Controls | Mean mucus flow rates for nasal septum were slower (0.91–1.2 mm/min) compared to rates on the lateral wall (3.61–8.15 mm/min); lateral wall mucus flow by region (slowest to fastest): anterior, midregions, posterior
| 18.5 mg/m^3^ (no recovery period) | Ciliastasis and mucostasis observed in specific regions of nose with discernible differences between recovery and nonrecovery groups; ciliastasis increased progressively with duration of exposure and was observed on anterior and ventral septum, anterio-medial and dorsal maxilloturbinate, and lateral wall and lateral nasoturbinate; distribution of mucostasis exhibited greater variation within exposure groups compared to ciliastasis; mucostasis exhibited similar site specificity as ciliastasis but with greater coverage than ciliastasis (<1 to several mm posterior to regions of ciliastasis); mucus flow observed over areas of ciliastasis in anterio-medial and anteriodorsal maxilloturbinate, anterior lateral wall, and anterior septum; mean mucus flow rates reduced in areas of nasal septum and lateral wall with intact mucociliary function
| 18.5 mg/m^3^ (90-min or 6-hr exposure with 1-hr recovery period) | 90-min group: recovery characterized to be almost complete, ciliastasis confined to small regions of anterio-ventral septum, anterio-medial maxilloturbinate, anterio-lateral nasoturbinate, and adjacent lateral wall; extent of ciliastasis similar to 18.5 mg/m^3^, 20-min group 6-hr group: recovery characterized as considerable but incomplete, especially in posterior regions of nose; reduced mucus flow rates compared to equivalent regions in control rats
| 2.5 mg/m^3^ | No evidence of impaired mucociliary function
Morgan et al. (1986c) (Fischer 344 rats; male; 6 exposed and 12 controls (n=6) morning, n=6 afternoon)/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 1, 2, 4, 9, or 14 d. Exposure was followed by an 18hr recovery period for some groups.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.57 (0.5–0.6; range), 2.46 (2.4–2.7), 7.27 (7.0–7.5), and 17.7 (15.0–18.5) mg/m^3^.^a^; Mucociliary function and mucus flow rate evaluated by using dissected nasal mucosa within 20 min after death.; Histopathologic evaluation of the respiratory tract included transverse sections of the nasal mucosa tissues used in the evaluation of mucociliary function.; Figure 1 from Morgan et al. (1986b) depicting rat nasal passages opened near the midline. Septum was removed to reveal turbinates. Arrows indicate direction of mucus flow, and numbers represent areas assessed for mucus flow rate. Inset represents lateral aspect of nasoturbinate showing lateral scroll.; Main limitations: No major limitations | Changes in mucociliary function
| Group | Observations (truncated from original article)
| Controls | Mucociliary apparatus functioned for 20–60 min after death; minimal inter-animal variation in mucus flow rate
| General observations for exposed groups | Concentration- and duration-related defects included cessation or severe slowing of mucus flow (mucostasis), loss of ciliary function (ciliastasis), or alterations in mucus flow patterns; minimal interanimal variation; mucostasis observed to generally be more extensive than ciliastasis, mucus was found flowing over areas of inactivated cilia
| 17.7 mg/m^3^ | Duration-dependent mucostasis most frequently observed on dorsal and medial aspects of maxilloturbinate, lateral aspect of nasoturbinate (especially lateral scroll), lateral ridge, and lateral wall; little or no recovery 18 hrs after exposure
| 7.27 mg/m^3^ | Changes were much less extensive as those in 17.7 mg/m^3^ group
| 2.46 mg/m^3^ | Changes were characterized as minimal or absent; localized inhibition of ciliary activity for few animals was observed on ventral margin of nasoturbinates with 9 days of exposure
| 0.57 mg/m^3^ | No inhibition of mucociliary function observed
| Changes in mucus flow rate
| Group | Observations
| Controls | No significant differences observed between morning and afternoon groups, combined for statistical analysis with exposed groups
| General observations | Mucus flow rates found to be characteristic of specific regions of the nose and observed to be slowest on anteromedial naso-and maxilloturbinates and anterior margin of ethmoid turbinate, fastest on lateral wall, and intermediate on other regions
| 17.7 mg/m^3^ | Reduction of mean mucus flow rate without histologic changes observed on ventromedial surface of nasoturbinate (area 1) after 1 d of exposure, with more pronounced and statistically significant reductions after 9 d of exposure even with 18 hrs of recovery
| 7.27 mg/m^3^ | No consistent changes in mucus flow rate observed except in areas with mucostasis
| 2.46 mg/m^3^ | No reduction in mucus flow rate observed; nonstatistically significant increases in mean mucus flow rates observed on posteromedial aspect of nasoturbinate (area 10)
| 0.57 mg/m^3^ | No reductions in mucus flow rate observed; statistically significant increases in mean mucus flow rate observed in areas 6 and 9 after 4 d of exposure but not after 9 d of exposure
Frogs
Low confidence
Morgan et al. (1984) Leopard frogs; male; 6/group.; Exposure: Frog palates were exposed to FA in an ex vivo chamber for up to 30 min after a 5min equilibration period.; Test article: Paraformaldehyde.; Actual concentrations were within 20% of nominal values and are reported for each endpoint in the Results column.^a^; Mucociliary function (i.e., mucus flow and ciliary activity) evaluated by using dissected frog palates.; Main Limitations: ex vivo, acute exposure; nonmamalian model | Group (± SE) | Initial response^a^ to exposure^b^ | Mucus stasis^b^ (min ± SE) | Ciliastasis^b^ (min ± SE)
| 11.8 (±0.37) mg/m^3^ | 6/6 | 6/6 (1.93±0.13) | 6/6 (3.47±0.44)
| 5.36 (±0.36) mg/m^3^ | 6/6 | 4/6 (8.14±3.27)^c^ | 4/6 (13.6±5.18)^c^
| 1.69 (±0.10) mg/m^3^ | 6/6^d^ | 0/6 | 0/6
| 0.28 (±0.04) mg/m^3^ | 0/6 | 0/6 | 0/6
| ^a^ Response was increased ciliary activity in the presence or absence of increased mucus flow rate.; ^b^ Number of cases in which change was observed/number of cases examined.; ^c^ Values in parentheses indicate time to induce the effect for the four positive cases.; ^d^ The response was variable and generally very slight in this group.
| Group mg/m^3^ (± SE) | Observations for mucociliary function (truncated from original article)
| 11.8 (±0.37) | Increased ciliary activity and mucus flow rate; peak mucus flow rate followed by rapid decline, cessation of flow, beating cilia, and changes to mucus flow; ciliastasis preceded by reduced beat frequency and amplitude
| 5.36 (±0.36) | Considerable inter-animal variation observed
| 1.69 (±0.10) | Inter-animal variation observed; initial response involved variable increase in mucus flow rate and increased ciliary activity or more frequent surges of increased activity
| 0.28 (±0.04) | No apparent effect after 30-min exposure
| 0 | Very few ciliated cells observed to be actively beating; any ciliary beating occurred in individual or small groups of cells; basal mucus flow rate determined to be 0–4 mm/min

As = anterior septum.

a Study authors originally reported FA concentrations in ppm. These values were converted based on 1 ppm = 1.23 mg/m^3^, assuming 25°C and 760 mm Hg.

Table C-29 Mucociliary function studies in humans

Study and design | Exposure | Results
Medium Confidence
Andersen and Molhave (1983); Denmark; Controlled Human Exposure Study; Participants: 16 healthy students, 5 females and 11 males. Mean age: 23 years; range 20–33 years. 31% smokers with one heavy smoker having >20 cigarettes per day. None had past formaldehyde exposure and all had healthy upper airways.; All were habitually nasal breathers with no history of chronic or recent acute respiratory disease.; Methods: Three identical sets of subject measurements taken each day, first during control period, second after 2–3 hrs of exposure and third after 4–5 hrs of exposure. Nasal mucociliary flow measurements in slits 1–2 are most anterior and slits 5–6 are most posterior part of the ciliated nose. ANOVA significance at 5%.; Main limitations: short exposure duration; note: internal control | A 5-hr exposure study. Subjects assigned to four groups, each group undergoing four different exposures over 4 consecutive days. Levels were 0.3, 0.5, 1.0 and 2.0 mg/m^3^ formaldehyde with order decided by latin square design. Each day began with 2 hr control period using clean air at 23 ± 0.5^o^C, 50 ± 5 % humidity, air velocity 10 ± 3cm/s and air supply rate of 500 m^3^/h. Control air comprised of outdoor air filtered through absolute and charcoal filters. Following control period, formaldehyde was added to air, reaching steady state concentration after one hour. Formaldehyde generated by passing air through an 80^o^C oven containing paraformaldehyde. Variation monitored, ranging within ±20% from the target values. | A statistically significant decrease in mucus flow rate occurred in the anterior two-thirds portion of the ciliated nose (slits 1–4). Mucus flow rate shown to decrease with increasing formaldehyde concentrations starting at 0.3 mg/m^3^ and then leveling off after 0.5 mg/m^3^. Flow rate decreases did not fluctuate with time of exposure.
Low Confidence
Holmström and Wilhelmsson (1988); Sweden; Prevalence Study; Population: Two exposed groups 170 total; 70 formaldehyde production workers, Mean age 36.9 years, 87% male, mean duration employment 10.4 year. 100 workers exposed to wood dust and formaldehyde at five furniture factories. Mean age 40.5 years, 93% male, mean duration employment 16.6 year. Referent: 36 persons from local government in the same village as the furniture workers, with no history of occupational exposure to formaldehyde or wood dust. Mean age 39.8 years, 56% male, mean duration employment 11.4 year.; Methods: Pretesting questionnaire, Mucociliary activity tested using green dye spotted on both inferior turbinates 1 cm posterior to the anterior border of the turbinate. Measured transit time of spot to rhinopharynx.; Chi-square tests or 2-tailed t-test for group comparisons.; Main limitations: poor matching of referent group (i.e., different occupation type; lower proportion of males); inclusion of only current workers and long duration of employment raises possibility of healthy worker effect due to irritation effects; crude measure. | Personal sampling in breathing zone for 1–2 hours in 1985. Total dust and respirable dust also measured. Previous measurements 1979-1984 in chemical company combined with 1985 values to estimate average annual values for each participant. Only 1985 values available for wood factories.; Formaldehyde concentration: Chemical plant: 0.05–0.5 mg/m^3^, mean 0.26 [SD 0.17 mg/m^3^]. Furniture factory: 0.2-0.3 mg/m^3^, mean 0.25 [SD 0.05 mg/m^3^]. Referent mean 0.09 mg/m^3^ (based on 4 measurements in 4 seasons). | Mucociliary clearance is defined to be pathological if transit time is > 20 minutes for one or both spots. In formaldehyde only group, 20% of subjects (14/69, p <0.05 compared to referent) had clearance times > 20 minutes compared to 15% of the formaldehyde-dust group (14/95) and 3% of the referent group (1/36).; Formaldehyde-only nasal specimens had higher mean score of 2.16 (range 0–4) (p <0.05) while formaldehyde-dust group had mean score 2.07 (range 0–6) (p >0.05). Referent group score was 1.56 (range 0–4). Combining formaldehyde-only and formaldehyde-dust group mean score 2.11 (p <0.05). No correlation observed between smoking habits and biopsy score, nor was a correlation found between the duration of exposure and any histological changes.

#### Synthesis on Cellular Proliferation in the Respiratory Tract

A number of quantitative cellular proliferation studies have been carried out in experimental animals, primarily in rats (see Figure C-22 and Tables C-30 and C-31). While these experiments provide more robust quantification of changes in cell number compared to histological determinations of tissue hyperplasia, the data provided by these approaches are limited to active proliferation and do not directly inform cumulative proliferative responses. For example, the most common approaches involve in vivo administration of either bromodeoxyuridine (BrdU, a thymidine analog) or tritiated thymidine ([^3^H]-thymidine), both of which label newly-synthesized DNA in dividing cells. When either of these are administered during the last 1–3 days of an exposure (nearly all of the studies followed a similar protocol), these experiments would only be able to measure the proliferation actively occurring during the 1–3 days at the end of the exposure; they would provide no information on proliferation induced earlier during the exposure period, or on adaptive changes to proliferative responses that might have resulted from those initial exposure effects. Despite this limitation, these studies still provide useful information on the magnitude of acute proliferation induced at different concentrations and following different durations of formaldehyde exposure. In addition, in some studies, histopathology was assessed along with cell proliferation, which may inform potential correlations between cellular proliferation and apical tissue pathology endpoints. The studies generally assessed cell proliferation in the anterior part of the nasal cavity, focusing on discrete regions (i.e., cross section levels) of the epithelium, with a few studies extending their investigation beyond the nasal cavity to include the trachea, larynx, and carina. There were notable differences in methodology across studies, including the use of different DNA synthesis-labeling agents (i.e., BrdU, [^3^H] thymidine, ^14^C), different durations of labeling (i.e., 2 hours to 3 days), and different measures of proliferation (i.e., cell turnover; ^14^C incorporation; labeling index [LI]: the ratio of labeled cells to total counted cells; unit length labeling index [ULLI]: the ratio of labeled cells per mm of basement membrane). While these methodological differences complicate direct comparisons across studies, increases in cell proliferation were in general consistently observed across several rat strains, with supportive findings in smaller databases of mice and monkey studies. Proliferation responses, at least in the anterior nasal cavity of exposed rats, were concentration-dependent, while in most studies the response magnitude remained relatively constant across exposure duration (i.e., acute proliferation responses were not notably larger after longer exposure at similar concentrations; see Figure C-22); the only study to test proliferation beyond 13 weeks of exposure suggested that response magnitude may actually begin to decrease in most nasal regions after chronic exposure (Monticello et al., 1996).

As illustrated in Figure C-22, after ≤1 week, 1–6 weeks, or ≥12 weeks of exposure, proliferation in the nasal epithelium was increased in a concentration-dependent manner in F344 rats, and from a more limited set of studies, in Wistar rats. Proliferation was also shown to increase in single studies of rhesus monkeys (after exposure for either 1 or 6 weeks to 7.38 mg/m^3^ formaldehyde; (Monticello et al., 1989)) and B6C3F1 mice (after exposure for 1 to 5 days at approximately 18.45 mg/m^3^ formaldehyde; (Swenberg et al., 1983b; Chang et al., 1983)). Interestingly, as with other respiratory tract effects, mice might be less sensitive to changes in cellular proliferation, although the data relevant to this interpretation are sparse. Specifically, proliferation in the epithelium lining nasal associated lymphoid tissue (NALT) was observed in F344 rats, but not in B6C3F1 mice, even at concentrations as high as 18.4 mg/m^3^ (Kuper et al., 2011). This potential difference could reflect the differential sensitivity to reflex bradypnea across species (see Appendix C.2). In rats, although the data were variable across studies, particularly in Wistar rats exposed for ≤ 1 week (Zwart et al., 1988; Woutersen et al., 1987; Wilmer et al., 1989; Reuzel et al., 1990; Cassee and Feron, 1994; Cassee et al., 1996b), the levels of cell proliferation in regions such as the anterior lateral meatus were typically 1.5- to 25-fold greater than control levels after exposure to ≥ ≈12 mg/m^3^ formaldehyde, regardless of exposure duration. While levels were similarly increased at ≈6–7.5 mg/m^3^ after exposure durations ≤ 13 weeks, the only study to evaluate longer exposures observed less robust increases in proliferation after chronic exposure, as compared to proliferation levels after 3 months of exposure (Monticello et al., 1996). The results across studies were less consistent at formaldehyde concentrations below 4 mg/m^3^, with several studies at 2.5–3.67 mg/m^3^ indicating that proliferation tended to increase in some nasal regions after ≥12 weeks (Zwart et al., 1988; Meng et al., 2010; Andersen et al., 2010)^16^ and others suggesting elevations in proliferation at concentrations ranging from 1.24–3.69 mg/m^3^ with exposure ≤ 1 week (Zwart et al., 1988; Roemer et al., 1993; Reuzel et al., 1990), although not all comparisons in all regions evaluated were statistically significant. Changes at these concentrations were not observed in several other studies of similar exposure duration, or in any studies examining 1–6 weeks of exposure. Increases in proliferation were typically not observed at formaldehyde concentrations below 1.23 mg/m^3^, although some weak induction was noted in a few studies.

Proliferation generally exhibited a decreasing anterior to posterior gradient and correlated with sites of respiratory tract pathology. For example, after adjusting for the number of animals with accurate tumor localization and including target cell population size in the comparison, increased cell proliferation was correlated (R^2^ = 0.88) with the incidence of squamous cell carcinoma; however, cell proliferation alone (i.e., without considering target cell population size) was not as well correlated (Monticello et al., 1996), suggesting that some minimal cell population size may be important for tumor formation. Cell proliferation has also been shown to be correlated with hyperplasia and squamous metaplasia; nasal lesions indicative of cytotoxicity such as cell degeneration, necrosis, or erosion and/or inflammation (Speit et al., 2011b; Monticello et al., 1991; Andersen et al., 2008; Andersen et al., 2010). Although most studies demonstrated proliferation in anterior regions of the nasal cavity, primarily examining sections at cross level 2 (variably including anterior and/or medial portions of structures such as the lateral meatus, maxilloturbinate, and nasoturbinate), some studies demonstrated formaldehyde-induced changes in more posterior regions, including regions outside of the URT. For example, exposure of groups (n = 3) of rhesus monkeys to 7.36 mg/m^3^ for 1 or 6 weeks resulted in increased proliferation along with slight histological changes (e.g., inflammation, hyperplasia, and metaplasia) in both the nasal cavity and extranasal regions including the larynx, trachea, and carina, but not the bronchioles (Monticello et al., 1989). In F344 rats, increased proliferation was observed in the nasopharynx at ≥12.3 mg/m^3^ (with slight increases at 2.48 mg/m^3^) after 4 weeks of exposure (Speit et al., 2011b). Increased proliferation in the trachea and lung was observed in SD rats following 1 or 3 days of exposure to 24.6 mg/m^3^, with mixed findings at lower concentrations, including increased proliferation in the trachea at 2.5mg/m^3^ after 1 day of exposure, but decreased proliferation in the trachea with 3 days of exposure at 2.5–7.4 mg/m^3^ (Roemer et al., 1993).

These latter data highlight the complicated nature of the association between formaldehyde exposure duration and cellular proliferation. While, generally, proliferation appears to be sustained at similar levels across exposure durations ranging from 1 day to 13 weeks (see Figure C-22), some studies reported differences in the magnitude of effects in specific regions of the respiratory tract tissue after different exposure durations. In studies of F344 and Wistar rats exposed to a wide range of formaldehyde concentrations (0.37–18.5 mg/m^3^), proliferation induced by formaldehyde exposure was typically not increased with longer exposure duration (in some instances, it was slightly decreased, but statistical comparisons were not performed) in various anterior nasal sections (approximately levels I–III), including comparisons of 3 days to 10 days (Swenberg et al., 1983b; Chang et al., 1983), 5 days to 15 days (Andersen et al., 2008), and 4 days to 6 weeks (Monticello et al., 1991) in F344 rats (note: response magnitude increased from 1 to 4 days in the latter study) and comparisons of 3 days to 4 weeks (Wilmer et al., 1987) and 3 days to 13 weeks in Wistar rats (Zwart et al., 1988). In several of these studies, the data suggest that formaldehyde concentration had a much greater impact on proliferation than exposure duration, although the relative contributions of concentration versus duration could not be accurately defined (Wilmer et al., 1987, 1989; Swenberg et al., 1983b; Chang et al., 1983). Somewhat complicating this, an increasing magnitude of proliferation at the same formaldehyde concentration was observed in anterior nasal regions of F344 rats exposed to 7.4–18.5 mg/m^3^ for 13 weeks, as compared to 1 or 4 weeks (Andersen et al., 2010), or for 5 days, as compared to 1 day (Chang et al., 1983), although an increase was not observed in B6C3F1 mice in the latter study. Similarly, in a study of rhesus monkeys, there was a noted exposure duration-dependent increase in proliferation in more posterior regions (approximately nasal section levels III–V as well as regions posterior to the nasal cavity) at 7.4 mg/m^3^ from 1 to 6 weeks of exposure (Monticello et al., 1989). Interestingly, while duration-dependent increases in proliferation were observed in anterior nasal regions of F344 rats exposed to 0.86–18.5 mg/m^3^ for 1–13 weeks, cell proliferation was greatest at 4 weeks, as compared to 1 or 13 weeks, when examining central and posterior portions (levels 2–3) of the nasal cavity (Meng et al., 2010). Finally, as previously mentioned and of particular interest, are the results of Monticello et al. (1996) in F344 rats exposed to 0.85–18.4 mg/m^3^ formaldehyde. The authors observed decreases in proliferation when comparing 3 months of exposure with longer durations up to 18 months within most of the nasal regions examined, including the lateral meatus, the anterior and posterior mid-septum, and medial maxilloturbinate; however, the opposite finding (i.e., duration-dependent increases in proliferation) was observed in the anterior dorsal septum (Monticello et al., 1996). Overall, the pattern across studies is mixed but indicates region-specific differences in the impact of exposure duration on proliferation.

A large number of well-conducted studies have evaluated acute cellular proliferation after exposure to a wide range of formaldehyde concentrations for durations ranging from 1 day to 18 months. The data were variable across studies. This variability is assumed to result, at least in part, from methodological factors that include the selection and preparation of tissue for analysis, the composition and administration protocol of the labeling agent used to indicate proliferation, when the proliferation counts were made (e.g., age of the animal), and the units used to express proliferation data (e.g., LI versus ULLI) (Monticello et al., 1993; Monticello and Morgan, 1997; Goldsworthy et al., 1991; Goldsworthy et al., 1993). Despite this methodological variability, cell proliferation was consistently increased in response to formaldehyde exposure in anterior portions of the rat, mouse, and monkey nasal cavity, with studies in rats demonstrating a prominent role for formaldehyde concentration. While some studies in rats and monkeys demonstrated a role for exposure duration in cell proliferation within specific regions of the respiratory tract, acute proliferation in most nasal regions generally remained constant regardless of exposure duration. The variability in the labeling index data in (Monticello et al., 1991; Monticello et al., 1996) is extensively characterized in Section D.2.2 “Characterization of uncertainty-variability in cell replication rates.”

Figure C-22 Nasal cell proliferation in rats exposed to formaldehyde

Summary of rat studies of nasal cell proliferation (as % change relative to controls) following different durations of formaldehyde exposure, specifically ≤1 week (left panel), 1–6 weeks (center panel), or ≥ 12 weeks (right panel). The tables below each panel summarize the studies, study confidence determinations (only high and medium confidence studies are shown), exposure durations, nasal regions depicted, cell labeling methods used, and the method of data reporting for each corresponding panel. Note: solid symbols indicate statistical significance, as identified by the study authors. High confidence studies are indicated by bolder symbols and with solid, rather than dashed, connecting lines. Data at different timepoints from the same study are indicated by use of the same line colors and general symbol shapes. See Tables C-30 and C-31 for additional details.

Table C-30 Subchronic or chronic exposure cell proliferation studies in experimental animals

Reference and study design | Results
Rats
High confidence
Andersen et al. (2010) Fisher 344; male; 8/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 1, 4, or 13 wks. Rats sacrificed immediately after last exposure.; Test article: Paraformaldehyde.; Actual concentrations reported in the Results column. Target concentrations were 0, 0.8, 2.5, 7.4, 12.3, and 18.5 mg/m^3^.^1^; Cell proliferation studies conducted with surgical implantation of BrdU-containing pumps (3 days prior to sacrifice) and determining labeling index at levels I (highest FA flux near nose tip), II (anterior lateral meatus, anterior mid-septum, medial aspect of maxilloturbinate), and III (posterior lateral meatus, posterior mid-septum). Cell proliferation at each site reported as number of labeled cells per total cells (i.e., LI) and as the number of labeled cells per length (i.e., mm) of basement membrane (i.e., ULLI).; Supplemental 4A from Andersen et al. (2010) depicting a schematic illustration of the nasal cavity levels used for cell proliferation studies. | Nasal Epithelium ULLI
| | Formaldehyde (mg/m^3^)
| Site | 0 | 0.8 | 2.5
| High-flux region (HFR)
| 1 week | 12.8±3.5^a^ (7)^b^ | 15.0±12.5 (8) | 13.8±7.0 (8)
| 4 weeks | 20.3±4.1 (7) | 17.8±3.8 (8) | 18.5±4.6 (5)
| 13 weeks | 21.9±20.3 (3) | 12.2±10.3 (3) | 29.1±32.7 (6)
| Anterior lateral meatus (ALM)
| 1 week | 31.9±26.3 (8) | 32.6±30.2 (8) | 25.1±26.1 (8)
| 4 weeks | 26.6±17.1 (8) | 34.3±21.3 (8) | 26.7±7.9 (8)
| 13 weeks | 21.7±15.1 (8) | 29.7±24.6 (8) | 56.3±33.3 (8)
| ^a^Mean ULLI±SD; ^b^Number of animals examined.
| Nasal Epithelium ULLI (continued)
| | Formaldehyde (mg/m^3^)
| Site | 0 | 7.4 | 12.3 | 18.5
| High flux region (HFR)
| 1 week | 12.8±3.5^a^ (7)^b^ | 25.2±13.3 (8) | 36.1±14.3^c^ (8) | 25.3±17.5 (7)
| 4 weeks | 20.3±4.1 (7) | 40.9±24.9 (5) | 69.2±17.7^c^ (6) | 63.6±26.1^c^ (8)
| 13 weeks | 21.9±20.3 (3) | 17.4 (1) | 58.3±27.8 (5) | 110.2±46.0^c^ (7)
| Anterior lateral meatus (ALM)
| 1 week | 31.9±26.3 (8) | 62.9±50.3 (8) | 75.7±31.1^d^(8) | 45.1±25.7 (8)
| 4 weeks | 26.6±17.1 (8) | 63.1±21.6^c^ (8) | 90.7±17.6^c^ (8) | 67.0±10.5^c^ (8)
| 13 weeks | 21.7±15.1 (8) | 56.4±17.2 (8) | 83.3±33.3^c^ (8) | 91.8±33.1^c^ (8)
| ^a^Mean ULLI±SD; ^b^Number of animals examined; ^d^p<0.01; ^e^p<0.05.
Meng et al. (2010); Fischer 344; males; 8/group.; Exposure: Rats were exposed to FA in dynamic chambers (not otherwise specified) 6 hrs/d, 5 d/wk for 1, 4, or 13 wks.; Test article: Paraformaldehyde.; Actual concentrations were not reported. Target concentrations were 0, 0.86, 2.46, 7.38, 12.3, and 18.5 mg/m^3^. | Dose-dependent increases in cell proliferation of nasal epithelium at 1, 4, and 13 wks of exposure.; Cell proliferation had a decreasing anterior to posterior gradient.; Duration-dependent increases in cell proliferation at the anterior portion of nasal cavity.; Cell proliferation greatest in the central and posterior regions of the nose following 4 weeks of exposure.
Cell proliferation studies conducted with surgical implantation of BrdU-containing pumps (3 d prior to sacrifice) and determining labeling index in the anterior lateral meatus (lateral wall) for both sides of the nose. Cell proliferation data reported as percentage of BrdU-labeled cells among the total number of labeled and unlabeled cells. | FA (mg/m^3^) | % BrdU-labeled cells after 13 wk
| 0 | 18
| 0.86 | 22
| 2.46 | 35
| 7.38 | 38
| 12.3 | 51^a^
| 18.5 | 64^a^
| ^a^p <0.01, compared to control group
Wilmer et al. (1989); Wistar rats; male; 25/group.; Exposure: Rats were exposed to FA in dynamic horizontally placed glass cylinders (with sampling ports at the inlet and outlet) either continuously for 8 hrs/d, 5 d/wk for 13 wks or intermittently 8 hrs/d (successive periods of 0.5 hr of exposure and 0.5 hr of nonexposure), 5 d/wk for 13 wks.; Test article: Paraformaldehyde.; Actual concentrations were not determined. Target concentrations were 0, 1.2, or 2.5 mg/m^3^ for continuous exposures and 0, 2.5, or 4.9 mg/m^3^ for intermittent exposures.^1^; Cell proliferation studies carried out after 3 d or 13 wks of FA exposure with [^3^H]thymidine labeling (ip injection 18 hrs postexposure) and scoring of the cells lining the nasal (n=1,000) and maxillary (n=1,000) turbinates and the septum (n=3,000). | Percentage of [^3^H]thymidine labeled cells in nasal epithelium
| | | % labeled cells
| Exposure | Exposure x time | After 3d | After 13 wk
| 0 mg/m^3^ | 0 mg/m^3^ hr/d | 0.60 (0.37)^a^ | 1.03 (0.26)
| 1.2 mg/m^3^ (continuous) | 9.6 mg/m^3^ hr/d | 0.34 (0.10) | 0.81 (0.54)
| 2.5 mg/m^3^ (continuous) | 20 mg/m^3^ hr/d | 0.61 (0.28) | 0.91 (0.59)
| 2.5 mg/m^3^ (intermittent) | 10 mg/m^3^ hr/d | 0.29 (0.20) | 1.16(0.59)
| 4.9 mg/m^3^ (intermittent) | 19.6 mg/m^3^ hr/d | 0.58 (0.32) | 2.86 (1.80)
| ^a^SDs shown in parentheses.
Zwart et al. (1988) Wistar rats; male and female; 50/group/sex.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/day, 5 d/wk for 13 wks.; Test article: Paraformaldehyde. Actual concentrations were 0, 0.37 (±0.02), 1.24 (±0.10), and 3.67 (±0.27) mg/m^3^.^1^; Cell proliferation studies carried out after 3 d or 13 wks of FA exposure with [^3^H]thymidine labeling (i.p. injection 18 hrs postexposure) and scoring of the cells lining the nasal and maxillary turbinates (n=1,500), septum (n=2,000), and lateral wall (n=1,500) at Section III. | Cell proliferation (based on 5 rats/group/sex); 3 days:; Section III - Exposure-related increase in cell turnover for combined data (males and female, p <0.001), with statistically significant differences between males and females (p <0.02).; Section II - Cell turnover statistically significant (p <0.001) in 3.67 mg/m^3^ group, no difference in 0.37 and 1.24 mg/m^3^ groups compared to controls.; 13 weeks:; Section III - Statistically nonsignificant decrease in mean cell turnover for all groups.; Section II - Cell turnover statistically significant (p <0.001) in 3.67 mg/m^3^ group, no difference in 0.37 and 1.24 mg/m^3^ groups compared to controls.; Compared to Section II, cell turnover roughly 10 times greater at Section III.
Only cells lining the nasal septum were scored at Section II. | Data extracted using Grablt software (mean+SEM converted from log scale):
Only cells lining the nasal septum were scored at Section II. | mg/m^3^ | Level III (3 d) | Level III (13 wk) | Level II (3 d) | Level II (13 wk)
Only cells lining the nasal septum were scored at Section II. | 0 | 0.517 (0.043) | 0.165 (0.029) | 0.022 (0.005) | 0.041 (0.014)
Only cells lining the nasal septum were scored at Section II. | 0.37 | 0.541 (0.045) | 0.133 (0.021) | 0.040 (0.008) | 0.038 (0.010)
Only cells lining the nasal septum were scored at Section II. | 1.24 | 0.872 (0.104)^*^ | 0.141 (0.027) | 0.034 (0.009) | 0.038 (0.005)
Only cells lining the nasal septum were scored at Section II. | 3.67 | 3.71 (0.442)^*^ | 0.101 (0.027) | 0.435 (0.147)^*^ | 0.214 (0.050)^*^
Medium confidence
Casanova et al. (1994); Fischer 344; male; 8/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 11 wks plus 4 d. On day 5 of week 12, rats were exposed to labeled FA (i.e., H^14^CHO) in nose-only chambers for 3 hrs.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.86 (±0.02), 2.52 (±0.05), 7.23 (±0.16), 12.35 (±0.23), 17.86 (±0.37) mg/m^3^ for whole body exposures and 0, 0.86 (±0.02), 2.53 (±0.04), 7.39 (±0.15), and 19.4 (±0.4) mg/m^3^ for nose-only exposures.; Cell proliferation studies carried out by determining H^14^CHO incorporation into DNA (i.e., de novo DNA synthesis) via liquid scintillation counting. | Cell proliferation lateral meatus (LM) versus medial and posterior meatuses (M:PM)^a^
| FA (mg/m^3^)^b^ | Observation
| 0 | NA
| 0.86 | No difference between LM and M:PM
| 2.53 | No difference between LM and M:PM
| 7.39 | Preexposed (PE) rats: significantly greater (p≤0.02) proliferation in LM than M:PM; Naive (N) rats: greater proliferation in M:PM than LM
| 19.4 | PE rats: significantly greater (p≤0.02) proliferation in LM than M:PM
| 19.4 | N rats: greater proliferation in M:PM than LM
| ^a^For whole body exposures to unlabeled FA, rats exposed to 0 mg/m^3^ were considered N, whereas rats in the other exposure groups were considered PE; ^b^Concentrations represent those used for nose-only exposures with H^14^CHO.
| Cell proliferation preexposed versus naïve rats^a^
| FA (mg/m^3^)^b^ | Observation^c^
| 0 | NA
| 0.86 | No difference between PE and N
| 2.53 | No difference between PE and N
| 7.39 | PE rats: greater (p <0.01) proliferation in LM than in N rats
| 19.4 | PE rats: greater (p <0.01) proliferation in LM and M:PM than N rats
| ^a^For whole body exposures to unlabeled FA, rats exposed to 0 mg/m^3^ were considered N, whereas rats in the other exposure groups were considered PE; ^b^Concentrations represent those used for nose-only exposures with H^14^CHO.
| ^c^Lateral meatus = L; medial and posterior meatuses = M:PM.
| Data extracted using Grablt software (mean+SEM):
| mg/m^3^ | Lateral Meatus (3h) | | Lateral Meatus (12 wk) | Med/Posterior Meatus (3d) | Med/Posterior Meatus (12 wk)
| 0.861 | 69.16 (0.0001) | | 74.93 (5.76) | 57.63 (5.76) | 63.40 (5.76)
| 2.46 | 80.69 (5.76) | | 92.22 (5.76) | 97.98 (0.0001) | 109.5 (5.76)
| 7.38 | 115.3 (5.76) | | 749.3 (161.4)* | 201.7 (23.05) | 276.7 (23.05)
| 18.45 | 149.86 (11.53) | | 1591 (132.5)* | 334.3 (23.05) | 1002 (103.7)*
| *p<0.05 for 12 wk vs 3 hr exposure
Monticello et al. (1996); F344 rats; male; 6/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers to FA 6 hrs/d, 5 d/wk for up to 24 mos with interim sacrifices at 3, 6, 12, and 18 mos. Test article: Paraformaldehyde.; Actual FA concentrations were 0 (±0.0), 0.85 (±0.06), 2.52 (±0.18), 7.39 (±0.41), 12.2 (±0.54), or 18.4 (±0.98) mg/m^3^.^1^; Cell proliferation studies (6 rats/group) conducted with surgical implantation of [methyl-^3^H]thymidine-containing pumps (5 days prior to interim sacrifice) and determining labeling index at 7 locations in the nasal passages: anterior lateral meatus, posterior lateral meatus, anterior mid-septum, posterior mid-septum, anterior dorsal septum, medial maxilloturbinate, and maxillary sinus (excluding ostium). Cell proliferation data reported as the number of labeled cell profiles per mm of basement membrane (i.e., ULLI). | mg/m^3^ | Exposure (mos) | Anterior lateral meatus | Posterior lateral meatus | Anterior mid-septum | Posterior mid-septum | Anterior dorsal septum
| 0 | 3 | 10.11^a^ | 7.69 | 6.58^a^ | 11.94 | 2.14
| 0 | 6 | 11.14 | 11.92 | 5.73 | 27.31 | 3.61
| 0 | 12 | 8.28 | 7.67 | 3.25 | 31.31 | 8.63
| 0 | 18 | 5.74 | 8.99 | 4.80 | 19.86 | 3.80
| 0.85 | 3 | 10.53 | 7.82 | 8.04 | 13.28 | 1.08
| 0.85 | 6 | 10.09 | 8.15 | 3.71 | 17.04 | 2.20
| 0.85 | 12 | 6.39 | 5.11 | 1.72 | 13.28 | 1.08
| 0.85 | 18 | 6.89 | 6.40 | 4.54 | 18.31 | 4.95
| 2.52 | 3 | 9.83 | 11.24^b^ | 12.74 | 13.11^b^ | 3.38
| 2.52 | 6 | 7.14 | 9.15 | 4.78 | 12.07 | 2.06
| 2.52 | 12 | 6.35 | 6.19 | 2.14 | 10.35 | 0.92
| 2.52 | 18 | 3.66 | 5.24 | 3.02 | 7.20 | 1.93
| 7.39 | 3 | 15.78 | 9.65 | 4.15 | 10.52 | 3.55
| 7.39 | 6 | 7.98 | 6.74 | 3.52 | 7.76 | 1.52
| 7.39 | 12 | 6.24 | 5.42 | 3.06 | 8.76 | 2.01
| 7.39 | 18 | 3.51 | 6.47 | 3.96 | 12.30 | 1.96
| 12.2 | 3 | 76.79 | 15.29 | 39.01 | 21.43 | 5.28
| 12.2 | 6 | 53.57 | 17.97 | 28.22 | 15.81 | 2.64
| 12.2 | 12 | 32.42 | 5.60 | 10.29 | 6.79 | 2.20
| 12.2 | 18 | 36.28 | 19.45 | 11.92 | 24.44 | 3.22
| 18.4 | 3 | 93.22 | 59.52 | 75.71 | 51.79 | 5.96
| 18.4 | 6 | 65.89 | 44.63 | 75.32 | 61.52 | 26.18
| 18.4 | 12 | 74.99 | 44.73 | 51.62 | 60.56 | 37.52
| 18.4 | 18 | 34.62 | 22.34 | 30.29 | 37.06 | 52.98
| ^a^n=5 or 6; ^b^n=4
| Exposure (mos) | mg/m^3^ | medial maxilla turbinate | maxillary sinus | mg/m^3^ | medial maxilla turbinate | maxillary sinus
| 3 | 0 | 7.84^a^ | 8.10 | 7.39 | 9.23 | ND
| 6 | 0 | 17.95 | ND | 7.39 | 10.18 | ND
| 12 | 0 | 7.85 | 6.31 | 7.39 | 6.22 | 12.04
| 18 | 0 | 5.58 | 5.95 | 7.39 | 5.03 | 9.51
| 3 | 0.85 | 10.33 | ND | 12.2 | 89.20 | ND
| 6 | 0.85 | 9.34 | ND | 12.2 | 57.83 | ND
| 12 | 0.85 | 6.79 | 7.80 | 12.2 | 43.27 | 9.15
| 18 | 0.85 | 5.08 | 6.99 | 12.2 | 42.74 | 12.12
| 3 | 2.52 | 10.84 | 3.12 | 18.4 | 115.19 | 10.77^b^
| 6 | 2.52 | 10.41 | ND | 18.4 | 101.97 | 13.13
| 12 | 2.52 | 5.98 | 7.73 | 18.4 | 66.64 | 17.06
| 18 | 2.52 | 3.42 | 8.52 | 18.4 | 63.11 | 13.16
| ^a^n=5 or 6; ^b^n=3

* p < 0.05 as reported by the study authors, unless otherwise indicated

Table C-31 Short-term exposure cell proliferation studies in experimental animals

Reference and study design | Results
Rats
High Confidence
Andersen et al. (2008); Fischer 344 rats; male; 8/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for up to 3 wks. Rats sacrificed at end of single 6-hr exposure (Day 1), 18 hrs after single 6-hr exposure (Day 1 recovery), at end of 5 d of exposure (Day 5), at end of 6 d of exposure (Day 6), 18 hrs after 6 d of exposure (Day 6 recovery), and at end of 15 d of exposure (Day 15).; Test article: Paraformaldehyde.; Actual concentrations were determined on a daily basis and reported in the Results column. Target concentrations were 0, 0.9, 2.5, 7.4, and 18.5 mg/m^3^.; This study also evaluated the effects of a single FA instillation (40 μL, 400 mM per nostril). Data presented here in the Results column are for inhalation exposures.; Cell proliferation studies conducted with surgical implantation of BrdU-containing pumps (3 d prior to sacrifice) and determining labeling index at levels I (front of nose), II (anterior lateral meatus, anterior septum, medial aspect maxilloturbinate), and III (posterior lateral meatus, posterior septum). Cell proliferation determined only for days 5 and 15 and reported as the number of labeled cell profiles per mm of basement membrane (i.e., ULLI). | Target concentration (mg/m^3^) | | | | Actual FA Concentrations^a^
| Target concentration (mg/m^3^) | | | | Day 1 (mg/m^3^) | Day 5 (mg/m^3^) | Day 6 (mg/m^3^) | Day 15 (mg/m^3^)
| 0 | | | | 0±0 | 0±0 | 0±0 | 0±0
| 0.9 | | | | 0.74±0.23 | 0.79±0.15 | 0.75±0.16 | 0.7±0.11
| 2.5 | | | | 2.08±0.46 | 2.14±0.43 | 2.26±0.49 | 2.2±0.31
| 7.4 | | | | 5.83±1.73 | 6.43±0.76 | 6.00±1.25 | 6.14±0.97
| 18.5 | | | | 17.7±5.7 | NA | NA | NA
| ^a^Daily means ± SD.
| Cell proliferation in nasal epithelium^a^
| | | | Formaldehyde (mg/m^3^)
| Day | Level | Site | Control | 0.9 | 2.5 | | 7.4
| 5 | I | NA | 38.6±8.5^b^; (13.2±4.6) | 36.8±14.7; (10.2±2.8) | 65.0±39.8; (16.6±6.0) | | 155.0±88.9^c^; (35.5±14.8)^c^
| 5 | II | Alm | 6.0±2.5 | 7.5±1.1 | 7.3±1.7 | | 29.0±21.9^c^
| 5 | II | As | 5.6±3.0 | 6.0±1.6 | 6.6±3.5 | | 14.2±10.3^c^
| 5 | II | Mam | 6.5±2.1 | 6.8±3.1 | 9.7±3.8 | | 35.1±22.0^c^
| 5 | III | Plm | 6.4±3.0 | 8.1±2.4 | 10.0±4.0 | | 16.1±6.4^c^
| 5 | III | Ps | 8.9±3.0 | 7.5±3.5 | 8.0±5.2 | | 15.0±11.9^c^
| 15 | I | NA | 78.9±54.7; (22.6±17.2) | 55.8±37.3; (15.6±10.5) | 50.8±44.2; (15.6±13.1) | | 119.1±38.0; (40.6±11)^c^
| 15 | II | Alm | 12.4±12.4 | 18.2±11.4 | 12.1±7.0 | | 19.1±8.7
| 15 | II | As | 12.0±9.7 | 17.6±11.0 | 10.0±4.6 | | 14.1±8.7
| 15 | II | Mam | 22.7±23.0 | 27.2±18.6 | 20.9±20.6 | | 21.9±16.8
| 15 | III | Plm | 11.8±10.0 | 12.6±6.3 | 11.7±7.6 | | 13.6±7.2
| 15 | III | Ps | 15.9±15.2 | 13.0±5.9 | 12.5±6.3 | | 18.3±12.1
| ^a^Reported as mean±SD; ^b^Data represent ULLI. Data in parenthesis represent LI: (labeled cells/total cells) × 100; ^c^p <0.05.
Cassee et al. (1996b); Wistar rats; male; 5 to 6/group.; Exposure: Rats were exposed to FA in dynamic nose-only chambers 6 hrs/d for 1 or 3 d. Rats sacrificed immediately after last exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0, 1.2, 3.9, and 7.9 mg/m^3^.; Cell proliferation studies carried out using deparaffinized standard cross sections of the nose and semiquantitative proliferating cell nuclear antigen (PCNA) immunostaining.; Cell proliferation studies were also conducted with surgical implantation of BrdU-containing pumps (20 hrs prior to sacrifice). Labeling index determined for the entire epithelium of both sides of anterior nasal cavity lining the nasoturbinate, maxilloturbinate, lateral wall, and septum. Cell proliferation at each site reported as number of positive-stained cells per length (i.e., mm) of basement membrane (i.e., ULLI).; Figure 1 from Cassee et al. (1996b) depicting cross levels of the rat nose evaluated for cell proliferation. | 1 d exposure: no treatment-related changes in cell proliferation
| FA (mg/m^3^) | | Cell proliferation measured by PCNA after 3 days^a^
| 1.2 | | Levels II and III: no increases in ULLIs
| 3.9 | | Level II: significant increase in ULLIs at maxilloturbinate (p <0.05) and nasal turbinate and lateral wall (p <0.01), compared to controls; Level III: no increases in ULLIs
| 7.9 | | NR
| ^a^Based on data from 3 to 5 rats per exposure group and 10 to 12 control rats.
| FA (mg/m^3^) | | Cell proliferation measured by BrdU after 3 days^a^
| 1.2 | | Levels II and III: no increases in ULLIs
| 3.9 | | Levels II and III: no increases in ULLIs
| 7.9 | | NR
| ^a^Based on data from 3 to 5 rats per exposure group and 10 to 12 control rats.
| This study also evaluated the combined effects of FA, acetaldehyde, and acrolein on nasal epithelium. Data presented here are for formaldehyde-only exposed rats
Chang et al. (1983); [additional data from related Swenberg et al. (1983b) report]; Fischer 344 rats; males; 4–5/exposure group, 9/control group.; Exposure: Rats were exposed to FA in head-only chambers 6 hrs/d for 1, 3, 5, or 10 d.; Test article: Paraformaldehyde.; Actual concentrations were 0 and 18.5 (±0.1) mg/m^3^. Target concentrations were 0, 0.62, 2.46, 3.69, 7.38, 14.76, or 18.45 mg/m^3^ in Swenberg et al. (1983b) report.; Cell proliferation studies carried out after FA exposure with [^3^H]thymidine labeling (i.p. injection 2 or 18 hrs postexposure) and scoring of cells (n=9,000) lining the respiratory epithelium from the nasal and maxillary turbinates and lateral wall.; Levels A (with minimal mucociliary clearance) and B (with extensive mucociliary clearance) reported in Swenberg et al. (1983b) | Group (18.5 mg/m^3^) | | | | Labeling index (%) in Level B
| Control | | | | 0.43±0.05 (9)^a^
| 1 day | | | | 5.51±0.35 (4)^b^
| 5 days | | | | 10.05±0.27 (5)^b, c^
| ^a^Number in parentheses represents number of animals studies; ^b^Significantly different from control, p<0.05; ^c^Significantly different from 1-d exposed rats, p<0.05.
| % labeled respiratory epithelial cells in Level B (thymidine at 2 h postexposure)
| | | Formaldehyde Concentration (mg/m^3^)
| Duration | | 0 | 0.62 | 2.46 | 7.38 | | 18.45
| 3 days | | 0.22 (0.03) | 0.38 (0.05) | 0.33 (0.06) | 5.4 (0.82) | | 2.83 (0.81)
| % labeled respiratory epithelial cells (thymidine at 18 h postexposure)
| | | | 3 d (Level B) | | 10 d (Level B) | | 3 d (Level A)
| Control | | | 0.54 (0.03) | | 0.26 (0.02) | | 3.0 (1.56)
| 3.69 mg/m^3^ × 12 hr/d | | | 1.73 (0.63) | | 0.49 (0.19) | | 16.99 (1.5)
| 7.38 mg/m^3^ × 6 hr/d | | | 3.07 (1.09) | | 0.53 (0.2) | | 15.46 (10.01)
| 14.76 mg/m^3^ × 3 hr/d | | | 9.0 (0.88) | | 1.73 (0.65) | | 16.49 (2.07)
| Mean (SEM); Group sizes and statistical comparisons not reported in Swenberg et al. (1983b); Note: Pulse labeling with thymidine 18 hrs compared to 2 hrs postexposure resulted in ≈2-fold and ≈3-fold increase in labeling in control rats and at 7.38 mg/m^3^, respectively (Swenberg et al., 1983b); .
Kuper et al. (2011); Fischer 344 rats; male; 8/group.; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 4 wks.; Test article: Formalin (10.21% FA).; Actual concentrations were 0, 0.63 (±0.06), 1.23 (±0.14), 2.48 (±0.18), 7.53 (±0.42), 12.3 (±0.48), and 18.4 (±0.06) mg/m^3^.; Cell proliferation studies conducted with surgical implantation of BrdU-containing pumps (3 d prior to sacrifice) and determining labeling index of 2 sections of NALT and 1 section of an upper-respiratory tract-draining lymph node (i.e., posterior and superficial cervical lymph nodes). Cell proliferation data reported as BrdU-positive cells per length (i.e., mm) of epithelium. | Lymph nodes: No FA-related effects on the number of BrdU-positive cells reported in the follicle and paracortex compartments and medulla
| BrdU counts in section 1 of NALT
| FA (mg/m^3^) | | Interfollicular area | | Interfollicular epithelium | | Follicular area | | Follicular epithelium
| 0 | | 61.9±18.8^a^ | | 6.5±3.2 | | 73.0±39.1 | | 12.6±17.5
| 0.63 | | 57.3±17.4 | | 4.9±2.2 | | 53.5±19.4 | | 4.9±3.8
| 1.23 | | 55.7±17.7 | | 5.9±3.4 | | 52.2±27.9 | | 6.4±6.5
| 2.48 | | 53.5±12.9 | | 4.3±2.7 | | 49.8±22.1 | | 4.7±3.2
| 7.53 | | 51.1±14.9 | | 3.3±2.4 | | 47.6±13.9 | | 5.8±5.3
| 12.3 | | 55.5±15.3 | | 5.5±3.5 | | 51.2±16.2 | | 5.7±2.9
| 18.4 | | 54.4±11.6 | | 28.2±11.1^b^ | | 41.4±14.2 | | 23.6±13.6^c^
| ^a^Mean number of BrdU-positive cells±SD; ^b^p <0.001; ^c^p <0.05.
| BrdU counts in section 2 of NALT
| FA (mg/m^3^) | | Interfollicular area | | Interfollicular epithelium | | Follicular area | | Follicular epithelium
| 0 | | 48.3±17.7^a^ | | 6.3±2.2 | | 62.3±24.1 | | 6.8±1.5
| 0.63 | | 51.0±16.3 | | 4.4±2.7 | | 58.0±30.5 | | 5.8±5.6
| 1.23 | | 53.9±12.2 | | 4.1±2.9 | | 47.0±15.3 | | 6.9±3.8
| 2.48 | | 53.4±14.2 | | 5.1±2.4 | | 52.2±15.1 | | 5.6±4.0
| 7.53 | | 48.2±12.3 | | 3.5±2.3 | | 47.2±15.0 | | 5.9±2.8
| 12.3 | | 56.0±16.3 | | 6.4±2.3 | | 56.8±17.4 | | 6.2±4.7
| 18.4 | | 49.9±9.1 | | 24.5±12.6^b^ | | 40.1±11.8 | | 22.9±10.5^b^
| ^a^Mean number of BrdU-positive cells±SD; ^b^p<0.001.
Monticello et al. (1991) Fischer 344 rats; males; 4–6/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 1, 4, or 9 d or 6 wks.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.85 (±0.01), 2.48 (±0.02), 7.63 (±0.12), 12.2 (±0.11), and 18.2 (±0.28) mg/m^3^.; Cell proliferation studies carried out after FA exposure with [^3^H]thymidine labeling (ip injection 18 hrs postexposure) and profiling nasal epithelial cells in serial sections of Levels II and III of the nose. Level II included the lateral meatus with the lateral aspect of the nasoturbinate, lateral wall, and lateral aspect of maxilloturbinate (Site 1); midseptum (Site 2); and medial aspect of maxilloturbinate (Site 3). Level III included the lateral wall (Site 1) and midventral septum (Site 2).; Figure 1 from Monticello et al. (1991). (A) Lateral view of the rat nose with Levels I–V of the nasal passage. (B) Level II and (C) Level III represent sites for cell proliferation studies. | Mean until length labeling indices^a^
| | | | Exposure time
| mg/m^3^ | Level | Site | 1 d | 4 d | 9 d | | 6 wks
| 0 | II | 1 | 2.16^b^ | 1.46 | 1.44 | | 0.91
| 0 | II | 2 | 1.08 | 1.03 | 1.09 | | 0.41
| 0 | II | 3 | 2.49 | 1.36 | 1.38 | | 1.02
| 0 | III | 1 | 1.83 | 1.10 | 1.36^c^ | | 0.98
| 0 | III | 2 | 3.02 | 2.81 | 1.68^c^ | | 2.18
| 0.85 | II | 1 | 1.31^c, e^ | 1.37 | 1.20 | | 0.88^c^
| 0.85 | II | 2 | 1.01^c^ | 0.97 | 0.80 | | 0.24^c^
| 0.85 | II | 3 | 1.75^c^ | 1.54 | 0.80 | | 1.21^c^
| 0.85 | III | 1 | 1.72^c^ | 1.27 | 1.40 | | 0.91^c^
| 0.85 | III | 2 | 1.74^c^ | 3.09 | 1.06 | | 1.54^c^
| 2.48 | II | 1 | 2.36^c^ | 1.72 | 1.73 | | 1.36
| 2.48 | II | 2 | 1.69^c^ | 0.67 | 0.97 | | 0.68
| 2.48 | II | 3 | 2.81^c^ | 1.09 | 1.48 | | 1.11
| 2.48 | III | 1 | 2.46^c^ | 1.09^c^ | 1.74 | | 0.86
| 2.48 | III | 2 | 2.39^c^ | 1.43^c^ | 1.43 | | 2.57
| 7.63 | II | 1 | 16.86^c, f, g^ | 30.51^f, g^ | 23.51^f, g^ | | 14.41^f, g^
| 7.63 | II | 2 | 3.85^c^ | 10.00^f^ | 10.85^f^ | | 2.10
| 7.63 | II | 3 | 18.15^c, f^ | 25.03^f^ | 22.54^f^ | | 16.32^f^
| 7.63 | III | 1 | 7.53^f^ | 8.77^c, f^ | 7.35^f^ | | 2.08
| 7.63 | III | 2 | 4.20 | 9.22^c, f^ | 9.50^f^ | | 2.58
| 12.2 | II | 1 | 11.17^c, f^ | 20.91^f^ | 28.59^f^ | | 23.87^c, f^
| 12.2 | II | 2 | 17.90^c, f^ | 26.12^f, g^ | 19.62^f^ | | 21.44^c, f, g^
| 12.2 | II | 3 | 5.87^c^ | 20.26^f^ | 20.95^f^ | | 26.07^c, f^
| 12.2 | III | 1 | 14.48^f^ | 20.01^c, f^ | 30.59^f^ | | 24.21^f^
| 12.2 | III | 2 | 24.44^f^ | 18.70^c, f^ | 28.60^f^ | | 13.98^f^
| 18.2 | II | 1 | 12.68^f^ | 25.78 ^f^ | 24.57^c, f^ | | 28.74^c, f^
| 18.2 | II | 2 | 16.72 ^f^ | 29.10 ^f^ | 29.09^c, f^ | | 25.95^c, f^
| 18.2 | II | 3 | 5.31 | 19.39 ^f^ | 28.71^c, f^ | | 25.10^c, f^
| 18.2 | III | 1 | 16.35^d, f^ | 30.80^c, f^ | 40.36 ^f^ | | 34.78^c, f^
| 18.2 | III | 2 | 19.26^d, f^ | 34.43^c, f^ | 32.53^f^ | | 27.47^c, f^
| ^a^Unit length labeling index defined as the number of labeled cell profiles/mm basement membrane; ^b^n=6, unless otherwise indicated; ^c^n=5; ^d^n=4; ^e^Unless noted, not statistically different from control; ^f^ p <0.05 compared to control; ^g^ p <0.05 compared to level III.
Reuzel et al. (1990); Wistar rats; male; 5/group.; Exposure: Rats were exposed in dynamic whole-body chambers 22 hrs/d for 3 d to FA.; Test article: Paraformaldehyde.; Actual concentrations were 0, 0.37 (±0.01), 1.4 (±0.0), and 3.8 (±0.1) mg/m^3^ FA.; Cell proliferation studies carried out after FA exposure with [^3^H]thymidine labeling (ip injection 2 hrs postexposure) and scoring of the cells lining the nasal (n=1,000) and maxillary (n=1,000) turbinates, lateral wall (n=1,000), and the septum (n=2,000).; See diagram from Cassee et al. (1996b) (above) for cross levels of the rat nose evaluated for cell proliferation. | Data extracted using GrabIt software (mean from level 2, Figure 3, HCHO only):
| mg/m^3^ | | Maxilloturb. | | Nasal Turb. | | Lateral wall | | septum
| 0 | | 0.351855128 | | 0.291340043 | | 1.19765084 | | 0.172349
| 0.369 | | 0.287744031 | | 0.842204054 | | 1.04583032 | | 0.221581
| 1.23 | | 0.221580704 | | 0.337503123 | | 0.54215496 | | 0.221581
| 3.69 | | 4.456151692* | | 5.273729396* | | 5.8261316* | | 4.627466*
| Note: data were also presented for Level 3 (same regions). While slight increases became noticeable at 3.69 mg/m^3^, none reached statistical significance.; This study also evaluated the combined effects of FA and ozone mixtures on nasal epithelium. Ozone co-exposure resulted in an increase in proliferation compared to formaldehyde exposure alone. Data are only presented herein for formaldehyde-only exposures.
Roemer et al. (1993); Sprague Dawley rats; male; 3 or 5/exposure group, 6 or 10/control group.; Exposure: Rats were exposed to FA in dynamic head-only chambers 6 hrs/d for 1 or 3 d.; Test article: Paraformaldehyde.; Actual concentrations were within 10% of nominal concentrations of 0, 2.5, 7.4, or 24.6 mg/m^3^. ^a^; Cell proliferation studies carried out after FA exposure with BrdU labeling (i.p. injection 16–22 hrs postexposure) and flow cytometry analysis of 10,000 cells per measurement. | Proportion of BrdU-labeled cells (%) after exposure
| | Formaldehyde (mg/m^3^)
| Cell origin and exposure frequency | Number of rats per group^a^ | 0 | 2.5 | | 7.4 | | 24.6
| Nose
| 1 exposure | 5 | 1.3 (0.1)^b^ | 2.4 (0.6)^c^ | | 3.7 (0.5)^c^ | | 2.7 (0.8)^c^
| 3 exposures | 5 | NR | 1.4 (0.3) | | 2.5 (0.2)^c^ | | 2.3 (0.2)^c^
| Trachea
| 1 exposure | 5 | 1.2 (0.1) | 3.1 (0.6)^c^ | | 2.1 (0.8) | | 2.8 (0.4)^c^
| 3 exposures | 5 | NR | 0.3 (0.1)^c^ | | 0.6 (0.1)^c^ | | 2.5 (0.2)^c^
| Lung
| 1 exposure | 3 | 1.8 (0.3) | 2.6 (0.6) | | 3.3 (0.4) | | 3.1 (0.7)
| 3 exposures | 3 | NR | 2.2 (0.0) | | 2.4 (0.7) | | 5.1 (1.5)
| ^a^Twice the number of rats in control groups; ^b^Standard error in parentheses;; ^c^Statistically significant at p ≤0.05, compared with controls.
Wilmer et al. (1987); Wistar rats; male; 10/group.; Exposure: Rats were exposed to FA (chamber type not reported) either continuously for 8 hrs/d, 5 d/wk for 4 wks or intermittently 8 hrs/d (successive periods of 0.5 hr of exposure and 0.5 hr of nonexposure), 5 d/wk for 3 d and 4 wks.; Test article: Paraformaldehyde. Actual concentrations were not determined. Target concentrations were 0, 6.2, or 12.3 mg/m^3^ for continuous exposures and 0, 12.3, or 24.6 mg/m^3^ for intermittent exposures.; Cell proliferation studies carried out after 3 d or 4 wks of FA exposure with [^3^H]thymidine labeling (ip injection 18 hrs postexposure) and scoring of the cells (n=5,000) lining the nasal and maxillary turbinates, the septum, and the lateral wall. | Percentage of [^3^H]thymidine labeled cells in nasal epithelium
| | | | | % labeled cells
| Exposure | | Exposure x time | | After 3 d of exposure (n=3) | | After 4 wks of exposure (n=3)
| 0 mg/m^3^ | | 0 mg/m^3^ hr/d | | 0.86 (0.14)^a^ | | 0.68 (0.12)
| 6.2 mg/m^3^ (continuous) | | 49.6 mg/m^3^ hr/d | | 2.82 (0.47)^b^ | | 1.33 (0.75)
| 12.3 mg/m^3^ (continuous) | | 98.4 mg/m^3^ hr/d | | 8.87 (1.51)^b^ | | 8.85^c^
| 12.3 mg/m^3^ (intermittent) | | 49.2 mg/m^3^ hr/d | | 9.80 (1.54)^d^ | | 3.41 (1.25)^e^
| 24.6 mg/m^3^ (intermittent) | | 98.4 mg/m^3^ hr/d | | 19.77 (2.39)^d^ | | 13.87 (0.64)^d^
| ^a^SDs shown in parentheses; ^b^p<0.01, compared to controls; ^c^Data from one rat; ^d^p<0.001, compared to controls; ^e^p<0.05, compared to controls.
Medium Confidence
Cassee and Feron (1994); Wistar rats; male; 20/group.; Exposure: Rats were exposed in dynamic nose-only chambers for 3 d (6 consecutive 12-hr periods of 8 hrs of exposure to FA followed by 4 hrs of nonexposure). Rats sacrificed immediately (i.e., within 30 min) after last exposure.; Test article: Paraformaldehyde.; Actual concentrations were 0 and 4.4 (SE ±0.1) mg/m^3^ FA alone. Cell proliferation studies carried out using deparaffinized standard cross sections of the nose and semiquantitative proliferating cell nuclear antigen (PCNA) immunostaining.; See diagram from Cassee et al. (1996b) (above) for cross sections of a rat nose examined for PCNA staining by Cassee and Feron (1994). | | | Controls | | | | FA alone^a^
| Site | | II^b^ | | III^b^ | | II | | III
| Nasoturbinates | | +^c^ | | + | | +++ | | +++
| Maxilloturbinates | | + | | + | | +++ | | +++
| Septum | | + | | + | | +++ | | +++
| Lateral wall | | + | | + | | +++ | | +++
| ^a^Only nonnecrotic areas at cross level II showed severe PCNA expression; ^b^Standard cross level II and III through the nose; ^c^PCNA-expression scores: +, some nuclei stained; ++, a moderate number of nuclei stained; +++, many nuclei stained.; In animals exposed to FA alone, no increased PCNA staining observed in olfactory epithelium.; This study also evaluated the combined effects of FA and ozone mixtures on nasal epithelium. Ozone co-exposure resulted in an increase in proliferation compared to formaldehyde exposure alone. Data are only presented herein for formaldehyde-only exposures.
Speit et al. (2011b); Fischer 344 rats; males; 6/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 4 wks.; Test article: Formalin (methanol concentration NR).; Actual concentrations were 0, 0.63 (±0.6), 1.23 (±0.14), 2.48 (±0.18), 7.53 (±0.42), 12.3 (±0.48), 18.4 (±0.06) mg/m^3^.; Cell proliferation studies conducted with surgical implantation of BrdU-containing pumps (3 days prior to sacrifice) and determining labeling index of 3 levels of the nasal cavity: I (nasal septum, lateral meatus [wall], maxilloturbinate, nasoturbinate), II (nasal septum, lateral meatus [wall]), and IV (nasopharynx). Cell proliferation data reported as BrdU-labeled nuclei per mm of basal lamina (i.e., ULLI). | ULLI for level III not assessed due to author’s expectation that this level was not a sensitive target tissue.
| ULLI for nasal level I
| mg/m^3^ | Nasal septum | | Lateral meatus | | Maxilloturbinate | | Naso-turbinate
| 0 | 6.64±1.30^a^ | | 8.44±3.37 | | 10.21±5.90 | | 14.15±2.93
| 0.63 | 8.02±2.57 | | 10.80±1.58^b^ | | 9.49±3.07 | | 17.13±6.97
| 1.23 | 6.04±2.20 | | 9.56±3.68 | | 10.43±5.52 | | 22.60±5.86^c^
| 2.48 | 6.14±3.15 | | 11.56±4.73 | | 9.08±2.65 | | 14.29±5.59
| 7.53 | 4.80±3.14 | | 14.85±2.40^c^ | | 12.95±3.94 | | 20.48±8.12^b^
| 12.3 | 3.83±2.13 | | 52.53±16.30^c^ | | 52.42±16.88^c^ | | 74.63±28.90^c^
| 18.4 | 70.86±14.30^c^ | | 74.21±16.37^c^ | | 81.96±2.90^c^ | | 67.50±12.76^c^
| ^a^Group mean value±SD; ^b^p<0.05; ^c^p<0.01.
| ULLI for nasal level II | | | | | ULLI for nasal level IV
| mg/m^3^ | Nasal septum | | Lateral meatus | | Naso-pharynx
| 0 | 14.59±6.37^a^ | | 9.33±4.22 | | 17.81±2.18^a^
| 0.63 | 19.93±7.66 | | 7.58±2.32 | | 21.23±5.19
| 1.23 | 22.36±7.04^b^ | | 8.04±2.92 | | 21.56±3.17
| 2.48 | 21.79±5.28^b^ | | 9.47±3.31 | | 21.33±3.55^b^
| 7.53 | 19.07±6.43 | | 9.28±3.54 | | 20.93±4.13
| 12.3 | 26.66±11.31 | | 37.13±5.22^c^ | | 29.23±4.25^c^
| 18.4 | 62.36±12.30^c^ | | 55.21±10.99^c^ | | 73.29±15.87^c^
| ^a^Group mean value±SD; ^b^p <0.05; ^c^p <0.01.
| Relative change (% control) in ULLI in metaplastic/ degenerative (M) and nonmetaplastic (O) epithelia
| | Nasal septum | | Lateral meatus | | Maxillo-turbinate | | Naso-turbinate
| mg/m^3^ | M | O | M | O | M | O | M | O
| Level I
| 12.3 | 58 | 61 | 622^a,b^ | 1195^a^ | 513^a,c^ | 262^a^ | 527^a,c^ | 139
| 18.4 | 1066^a^ | 1386^a^ | 879^a,c^ | 1399^a^ | 802^a^ | 735^a^ | 477^a,b^ | 280^d^
| Level II
| 12.3 | 183 | 161 | 398^a,c^ | 110 | NA | NA | NA | NA
| 18.4 | 428^a,c^ | 1188^a^ | 592^a,c^ | 195^a^ | NA | NA | NA | NA
| ^a^p <0.01, compared to corresponding untreated control; ^b^p <0.05, comparison between metaplastic and nonmetaplastic tissues; ^c^p<0.01, comparison between metaplastic and nonmetaplastic tissues; ^d^p <0.05, compared to corresponding untreated control.
Woutersen et al. (1987); Wistar rats; male and female; 10/sex/group.; Exposure: Rats were exposed to FA in dynamic whole-body chambers for 6 hrs/d, 5 d/wk for 3 d.; Test article: Paraformaldehyde.; Actual concentrations were 0, 1.2 (±0.00), 11.9 (±0.15), and 24.4 (±0.09) mg/m^3^.; Cell proliferation studies carried out after 3 d of FA exposure with [^3^H]thymidine labeling of dissected nasoturbinates (18 hrs postexposure) and scoring of the cells (n=1,000) of the respiratory epithelium. | Percentage of [^3^H]thymidine labeled cells in nasal epithelium (males, n=2/group)
| | | % labeled cells
| mg/m^3^ | | Visibly unaffected epithelium | | | Metaplastic epithelium
| 0 | | 1.6 (1.2–2.0)^a^ | | | NR
| 1.2 | | 1.2 (0.8–1.5) | | | NR
| 11.9 | | 2.6 (1.4–3.8) | | | 31.4 (29.5–33.2)
| 24.4 | | 2.8^b^ | | | 37.6 (32.6–42.5)
| ^a^Range in parentheses; ^b^Value based on one rat since most respiratory epithelium was metaplastic.
Mice
High Confidence
Chang et al. (1983) [additional data from related Swenberg et al. (1983b) report] B6C3F1 mice; males; 4–5/exposure group, 10/control group.; Exposure: Mice were exposed to FA in head-only chambers 6 hr/d for either 1, 3, 5 or 10 d.; Test article: Paraformaldehyde.; Actual concentrations were 0 and 18.5 (±0.1) mg/m^3^. Target concentrations were 0, 0.62, 2.46, 3.69, 7.38, 14.76 or 18.45 mg/m^3^in Swenberg et al. (1983b) report.; Cell proliferation studies carried out after FA exposure with [^3^H]thymidine labeling (ip injection 2 or 18 hrs postexposure) and scoring of cells (n=4,000) lining the respiratory epithelium from the nasal and maxillary turbinates and lateral wall.; See diagram from Swenberg et al. (1983b) for rats (above) for locations of Levels A (with minimal mucociliary clearance) and B (with extensive mucociliary clearance) | Group (18.5 mg/m^3^) | | | | Labeling index (%) in Level B
| Control | | | | 0.27±0.04 (10)^a^
| 1 day | | | | 2.14±0.56 (5)^b^
| 5 days | | | | 3.42±0.84 (4)^b^
| ^a^Number in parentheses represents number of animals studies.; ^b^Significantly different from control, p <0.05.
| % labeled respiratory epithelial cells in Level B (thymidine at 2 hr postexposure)
| | | Formaldehyde Concentration (mg/m^3^)
| | | 0 | 0.62 | 2.46 | | 7.38 | | 18.45
| 3 days | | 0.12 (0.02) | 0.09 (0.04) | 0.08 (0.04) | | 0.15 (0.06) | | 0.97 (0.04)
| % labeled respiratory epithelial cells in Level A (thymidine at 18 hr postexposure)
| Control | | | | 1.24 (0.57)
| 3.69 mg/m^3^ × 12 hr/d for 10 d | | | | 10.14 (3.20)
| 7.38 mg/m^3^ × 6 hr/d for 10 d | | | | 4.72 (1.61)
| 14.76 mg/m^3^ × 3 hr/d for 10 d | | | | 1.76 (0.49)
| Mean (SEM); Group sizes and statistical comparisons not reported in Swenberg et al. (1983b)
Kuper et al. (2011); B6C3F1 mice; females; 6/group.; Exposure: Mice were exposed to FA in dynamic whole-body chambers 6 hr/d, 5 d/wk for 4 wk.; Test article: Formalin (10.21% FA).; Actual concentrations were 0, 0.63 (±0.06), 1.23 (±0.14), 2.48 (±0.18), 7.53 (±0.42), 12.3 (±0.48), and 18.4 (±0.06) mg/m^3^.; Cell proliferation studies conducted with surgical implantation of BrdU-containing pumps (3 d prior to sacrifice) and determining labeling index of 2 sections of NALT and 1 section of an upperrespiratory tract-draining lymph node (i.e., posterior and superficial cervical lymph nodes). Cell proliferation data reported as BrdU-positive cells per length (i.e., mm) of epithelium. | NALT: No FA-related effects on the number of BrdU-positive cells reported in the follicular and interfollicular compartments and epithelium; Lymph nodes: No FA-related effects on the number of BrdU-positive cells reported in the follicle and paracortex compartments and medulla
Monkeys
Medium Confidence
Monticello et al. (1989); Rhesus monkeys; male; 3/group.; Exposure: Monkeys were exposed to FA in dynamic whole-body chambers 6 hrs/d, 5 d/wk for 1 or 6 wks.; Test article: Paraformaldehyde.; Actual concentrations were not determined. Target concentration was 7.4 mg/m^3^. Controls were sham exposed to biologically filtered air for 6 wks. Cell proliferation studies carried out after FA exposure with [^3^H]thymidine labeling (iv injection 18 hrs postexposure) and scoring of respiratory epithelial cells. For nasal passages (transitional, respiratory, and olfactory epithelia), larynx, trachea, and carina, LIs defined as the number of labeled cells per mm of basal lamina.; Figure 4 from (Monticello et al., 1989) depicting the nasal passage levels selected for cell proliferation studies. A, nasal atrium; B, anterior aspect of the middle and ventral turbinates; C, midregion of the maxillary sinuses; D, posterior nasal cavity; and E, nasopharynx. | Exposure | Observations between nasal passage epithelia
| Controls (6 wk) | Highest LIs in transitional epithelium compared to respiratory and olfactory epithelia
| 7.4 mg/m^3^ (1 wk) | Transitional and respiratory epithelia elevated compared to controls (p ≤0.05)
| 7.4 mg/m^3^ (6 wk) | Transitional epithelium LIs slightly elevated over controls and had decreased from 1-wk group; olfactory epithelium LIs had mild increase over controls (p ≤0.05); respiratory epithelium LIs elevated compared to controls (p ≤0.05)
| Exposure | Observations between levels of nasal passages
| Controls (6 wk) | LIs for Levels B–E significantly increased over controls (p ≤0.05), anterio-posterior gradient (i.e., greatest to lowest) in cell proliferation rates
| 7.4 mg/m^3^ (1 wk) | LIs for Levels B–E significantly increased over controls (p≤0.05)
| 7.4 mg/m^3^ (6 wk) | Levels C–E significantly elevated over 1-wk group (p ≤0.05)
| Group | Observations within levels of nasal passages
| Level A | NR
| Level B | LIs for 1- and 6-wk groups elevated over controls (p ≤0.05) for septum, inferior meatus, inferior turbinate, lateral wall, and middle turbinate
| Level C | LIs for 1- and 6-wk groups elevated over controls (p ≤0.05) for septum, inferior meatus, inferior turbinate, lateral wall, and middle turbinate; no increase in LIs for 1- and 6-wk groups over controls for maxillary sinuses
| Level D | LIs for 1-wk group elevated over controls (p ≤0.05) for septum, inferior meatus, inferior turbinate, and lateral wall; LIs for 6-wk group elevated over controls (p ≤0.05) for inferior meatus and inferior turbinate
| Level E | LIs for 1-wk group elevated over controls (p ≤0.05) for floor and lateral and dorsal walls; LIs for 6-wk group elevated over controls (p≤0.05) for septum, floor, and lateral and dorsal walls
| Group | Observations for nonnasal tissues
| Larynx | LIs for 1- and 6-wk groups elevated over controls; LIs increased with duration of exposure
| Trachea | Significant elevation in LIs for 1-wk (p ≤0.05) but not 6week group over controls; LIs increased with duration of exposure
| Carina | Significant elevation in LIs for 1-wk (p ≤0.05) but not 6-wk group over controls; LIs increased with duration of exposure
| Interanimal variation in LIs for trachea and carina
| Exposure | | Animal # | | Trachea LI | | Carina LI
| Controls (6 wk) | | 1 | | 0.29 | | 0.42
| Controls (6 wk) | | 2 | | 0.46 | | 0.37
| Controls (6 wk) | | 3 | | 0.91 | | 0.50
| Controls (6 wk) | | ave | | 0.55±0.19^a^ | | 0.43±0.04^a^
| 7.4 mg/m^3^ (1 wk) | | 4 | | 1.34 | | 1.09
| 7.4 mg/m^3^ (1 wk) | | 5 | | 0.90 | | 1.95
| 7.4 mg/m^3^ (1 wk) | | 6 | | 1.19 | | 0.99
| 7.4 mg/m^3^ (1 wk) | | ave | | 1.14±0.13^a^ | | 1.34±0.31^a^
| 7.4 mg/m^3^ (6 wk) | | 7 | | 8.00 | | 3.86
| 7.4 mg/m^3^ (6 wk) | | 8 | | 2.30 | | 6.49
| 7.4 mg/m^3^ (6 wk) | | 9 | | 0.88 | | 0.45
| 7.4 mg/m^3^ (6 wk) | | ave | | 3.73±2.18^a^ | | 3.60±1.75^a^
| ^a^Represents Mean±SEM.
| Exposure | | LI in respiratory bronchioles^a^
| Controls (6 wk) | | 0.01±0.001
| 7.4 mg/m^3^ (1 wk) | | 0.01±0.003
| 7.4 mg/m^3^ (6 wk) | | 0.01±0.001
| ^a^LIs expressed as percent labeled cells per total cell count from ≥500 respiratory bronchiolar nucleated epithelial cells per animal.

### C.7.2 Synthesis of Changes in the Lower Respiratory Tract (LRT)

Although the URT and the LRT are physically and functionally connected, this analysis delineates findings across these two tissue compartments. This was done due to the distribution of the overwhelming majority of inhaled formaldehyde to the URT (noting that some data suggest that oronasal breathing in humans, as compared to nose-only breathing in rodents, might result in slight differences in the distribution of inhaled formaldehyde, including a possible increase in the portion reaching proximal regions of the LRT such as the trachea; see additional discussion on toxicokinetics in Appendix C.1). Thus, evidence related to studies of BAL (bronchoalveolar lavage) fluid and airway function, both of which may involve some contribution from URT-related changes but are largely driven by effects on the lung, are described in this section. The specific studies and summary findings supporting the synthesis below are described in Table C-32 and are considered as part of the broader integration of MOA information in Figures C-23 and C-24. In general, compared to effects on the URT, the methodological approaches for evaluating LRT changes are more commonly applied to studies of exposed humans, so this section considers a wider range of evidence. A greater level of concern exists for the erroneous attribution of changes in the LRT (and other, non-URT, compartments in subsequent sections) to inhaled formaldehyde when studies used methanol-containing formalin; thus, findings from some studies using exposure paradigms similar to those described in the previous section are interpreted with comparably less confidence.

As previously mentioned, formaldehyde-induced stimulation of TRPA1 receptors on trigeminal nerve endings distributed within the epithelial cell layer in the URT appears to cause a localized release of neuropeptides, including substance P, which can cause local inflammatory changes. Consistent with this, ex vivo models of LRT tissues and low confidence studies of in vivo exposure suggest that indirect activation of sensory nerve endings in the LRT, presumably of the vagus nerve, occurs after formaldehyde inhalation exposure. In the URT, this activation is expected to occur via direct interaction of formaldehyde with receptors. However, while these direct interactions might occur in upper portions of the LRT during certain, very rare human exposure scenarios (e.g., in the trachea at high exposure levels), they would be unexpected in the lungs or during typical exposure scenarios; thus, this is not considered a plausible initial effect of typical exposure. Notwithstanding this assumption, the available evidence indicates that formaldehyde exposure likely causes downstream sequelae in the lung that could be attributed to sensory nerve activation in the LRT, predominantly related to substance P-related pathways (see below). However, the mechanistic event(s) critical to understanding this potential relationship remain unknown: namely, how sensory nerve endings in the LRT would be stimulated without distribution of inhaled formaldehyde to the LRT. The most likely explanations involve a secondary response to TRP channel-activating stimuli increased via other mechanisms, such as increased LRT oxidative stress and/or inflammatory mediators released from activated immune cells or damaged epithelial cells in the LRT. It could also be explained by a central trigeminal-to-vagal neural reflex response to irritation of the URT (i.e., a “nasobronchial” reflex^17^); however, the existence of this reflex in humans is debated and a clear scientific consensus does not exist (Togias, 1999, 2004; Sahin-Yilmaz and Naclerio, 2011; Giavina-Bianchi et al., 2016). No studies specifically designed to assess any of these potential linkages after formaldehyde exposure were identified.

Studies in several species provide moderate evidence that formaldehyde exposure results in increased LRT neuropeptides, including substance P (see “Changes in the URT” Section above), as well as a rapid activation of the primary receptor for substance P, the neurokinin receptor (NK_1_R), typically at formaldehyde concentrations ≥2.5 mg/m^3^. Further, the activation of this pathway has been experimentally linked to both formaldehyde-induced leakage of the LRT microvasculature (which has been observed in rodents at ≥1.23 mg/m^3^) as well as airway hyperresponsiveness (which has been observed in animals and humans at <0.5 mg/m^3^). In addition to facilitating the recruitment of inflammatory cells, NK_1_R activation can promote immune cell survival and activation through the release of cytokines and chemokines (Tuluc et al., 2009). The substance P-NK_1_R pathway has been implicated in mast cell degranulation, which can lead to bronchoconstriction (Bienenstock and Mcdermott, 2005); however, while inhibiting mast cell activation prevented microvascular leakage in a low confidence rat study after acute exposure to high levels of formaldehyde (Kimura et al., 2010), an acute medium or high confidence study of a cohort of guinea pigs failed to observe any changes in mast cells (Swiecichowski et al., 1993; Leikauf, 1992). Importantly, an understanding of potential changes to substance P and NK1R-dependent effects (e.g., due to desensitization) with long-term formaldehyde exposure remains unclear. While a transient depletion of neuropeptides from sensory nerve terminals after acute exposure seems plausible (Leikauf, 1992). Importantly, an understanding of potential changes to substance P and NK1R-dependent effects (e.g., due to desensitization) with long-term formaldehyde exposure remains unclear. While a transient depletion of neuropeptides from sensory nerve terminals after acute exposure seems plausible (Kimura et al., 2010), substance P is still elevated, at least in the blood, after subchronic exposure (Fujimaki et al., 2004b). Overall, the activation characteristics of this pathway in the LRT across various formaldehyde exposure scenarios have not been established.

Microvascular leakage can lead to inflammatory structural changes observable by histology, which are supported by moderate evidence in formaldehyde-exposed rodents, particularly those sensitized with the allergen, ovalbumin (OVA). The available studies indicate changes including airway edema (swelling) or thickening of airway walls, with general support for inflammatory changes in airway bronchi, but not necessarily alveoli. In addition, the pattern of structural changes varied across studies, with a study in guinea pigs observing airway swelling without signs of inflammation at low formaldehyde (<0.5 mg/m^3^) levels (Riedel et al., 1996), while studies in rats and mice generally observed mild inflammatory-related structural changes at higher levels (i.e., ≥3.0 mg/m^3^) that only became pronounced with allergen sensitization. It is important to note that animal models vary in their ability to mimic some features of human airways. Airway responses in guinea pigs often differ from those in rats and mice, and while no animal model fully recapitulates human airway function, in many ways the sensitivity of guinea pig airways may be more relevant than other small mammals (e.g., similar structure of the lung to humans; responsiveness to stimuli that induce sensitivity in humans) (Shin et al., 2009; Ricciardolo et al., 2008). Alongside airway inflammation and structural changes, including edema, which could narrow or obstruct airways, an increased permeability to bronchoconstrictors such as histamine would be expected to influence airway function, possibly linking these changes to observations of hyperresponsiveness or decreased pulmonary function.

A moderate association between formaldehyde exposure and increases in LRT eosinophils was identified, including amplification of the response of these cells in rodents previously exposed to allergens (see Table C-33). Taken together with similar findings in the URT, a general increase in airway eosinophils as a result of formaldehyde exposure is supported by robust evidence. As in the URT, this finding has been reported in the LRT following exposure for several weeks at effective concentrations above 0.5 mg/m^3^. The only study of longer-term exposure available (Fujimaki et al., 2004b) indicated that formaldehyde exposure at 2.46 mg/m^3^, but not ≈0.5 mg/m^3^, for 3 months caused increased eosinophils in mice sensitized to OVA, but not in unsensitized mice. While the data are not conclusive, it appears that eosinophil recruitment does not occur immediately after acute exposure, as this increase was not observed in the available studies of acute exposure (see Table C-33). Although it has not been mechanistically demonstrated based on increased eosinophils and other immune cells after acute tachykinin release (Barnes, 1992, 1998), repeated release of neuropeptides could plausibly lead to sustained airway inflammation and, depending on the phenotype of the recruited cells, this could result in airway hyperresponsiveness. In both the URT and LRT, recruitment of eosinophils might also be related to changes in markers of oxidative stress observed across formaldehyde exposure paradigms. However, whereas oxidative stress in the URT may be related to damage to the local epithelial cells, most studies indicate that formaldehyde exposure does not result in overt damage to the LRT airway epithelium (slight evidence, at relatively high formaldehyde levels: >5 mg/m^3^), making this potential linkage less plausible. It is considered more likely that increases in oxidative stress are the result of changes in inflammatory factors and immune cells in the LRT, rather than LRT epithelial damage.

The evidence for LRT immunological changes other than those seen in eosinophils is mixed and generally only suggestive of potential effects. As shown in Figure C-24, slight evidence exists to suggest that formaldehyde exposure amplifies recruitment of innate immune cells such as neutrophils and monocytes to the LRT; notably, this finding has only been observed when animals exposed to >2 mg/m^3^ were previously sensitized to an allergen. Importantly, few studies examined lymphocyte subsets, and no studies reported on the response of lymphocytes in animals sensitized to allergens or at exposure levels below 5 mg/m^3^, highlighting important gaps in the literature. Two studies suggest that CD8^+^, but not CD4^+^, T cells may be increased with formaldehyde exposure above 7 mg/m^3^ (Sandikci et al., 2007b; Jung et al., 2007). The only study meeting the inclusion criteria that evaluated lymphocyte changes in both immature and adult animals only observed changes in animals exposed as adults (Sandikci et al., 2007b), which could suggest that a functionally mature immune system is necessary for these alterations (the immune system is not considered to be fully mature in rodents until around six weeks of age (Burns-Naas et al., 2008)). While these findings should be interpreted with substantial caution, there may be a role for CD8^+^ T cells in promoting the recruitment and survival of airway eosinophils, as well as a requirement of these cells for the development of airway hyperresponsiveness (e.g., to allergen or infection) (Schwarze et al., 1999; Hamelmann et al., 1997). CD8^+^ T cells make up a heterogeneous population of lymphocytes which migrate by recruitment to sites of inflammation, proliferate in response to antigen stimulation, and help to mediate long-term cellular immunity against foreign pathogens, particularly viruses. The conventional role for IFNγ-producing CD8^+^ T cells is to inhibit eosinophil function; however, some emerging evidence suggests that certain CD8^+^ T cell subpopulations may induce eosinophil recruitment (Huber and Lohoff, 2015). No data are available to evaluate the potential for effects of formaldehyde exposure on different subpopulations of LRT CD8^+^ T cells.

Studies of markers of immune cell activation in the LRT after formaldehyde exposure generally provide mixed results, making it difficult to draw inferences (see Table C-33). Most cytokine-related changes reported in the LRT occur at high formaldehyde levels (>5 mg/m^3^) after short-term exposure and include slight evidence to support an increase in eosinophil chemotactic factors, and a decrease in markers and counts of natural killer (NK) cells. NK cells respond rapidly to infection and appear to have a role in regulating chronic inflammation and infection of the airways (FJ, 2009). Thus, this change, were it to be experimentally verified, could be associated with the moderate evidence of an increased propensity for LRT infections, similar to the slight evidence of altered URT immune responses (see previous section); however, definitive studies relevant to long-term exposure have not been identified and additional data are necessary to interpret these alterations in respiratory immune responses as consistent with immune suppression. A number of consistent studies in exposed rodents do suggest an increase in T helper type 2 (Th2)-related cytokines, most notably IL-4, with short term exposure at ≥0.5 mg/m^3^ and particularly in animals sensitized to an allergen. The slight evidence supporting increased IL-5, a Th2 cytokine that can be both synthesized by and act upon airway mast cells and eosinophils and which is believed to be integral to the development of airway eosinophilia and airway hyperresponsiveness (Schwarze et al., 1999; Greenfeder et al., 2001), is considered to be inconclusive (i.e., two low confidence studies testing exposure levels >5 mg/m^3^). Along with IL-5 and IL-13, IL-4 is recognized for its established role in chronic respiratory disorders (Maes et al., 2012), and this change may be relevant to other LRT-specific changes. IL-4, which can stimulate T cell receptors on CD4^+^ and CD8^+^ T cells (Serre et al., 2010), can influence the activation and development of antigen-specific CD8^+^ T cell immunity by shifting the phenotype of these cells from IFN-γ production to IL-4 production (Erb and Le Gros, 1996).

The cytokine changes could be related to the moderate evidence for increased LRT infections and the slight evidence suggesting reduced NK cell numbers (see Tables C-32 and C-33), as Th2 cytokines have been shown to reduce pulmonary bacterial immunity (Beisswenger et al., 2006) and NK cells have a role in regulating chronic inflammation and infection of the airways (FJ, 2009). A key limitation of the data is that the few formaldehyde-specific studies have not demonstrated consistent increases in CD4^+^ Th2 cells in the airways of exposed individuals. Similarly, interactions between airway innate and adaptive immune responses, and between CD4^+^ and CD8^+^ T cells, topics of current interest (Koya et al., 2007; Gasteiger and Rudensky, 2014), have not been well studied following formaldehyde exposure. Experiments focused on these types of endpoints would help to integrate the currently available data.

The consistent evidence of amplified airway responses to immunogenic stimuli (e.g., to allergens such as OVA) following formaldehyde exposure is of particular interest. As described above, multiple LRT parameters are affected or exacerbated by the combination of formaldehyde exposure and sensitization to allergenic materials. At concentrations ranging from 0.31–3 mg/m^3^ over durations of several days to several weeks, formaldehyde exposure in combination with allergen sensitization exacerbates immune-related changes, such as: recruitment of eosinophils and possible increases in IL-4; airway structural changes, including edema; and airway functional changes, including exaggerated responses to muscarinic receptor agonists. These observations may be relevant to the associations between human formaldehyde exposure at much lower concentrations (<0.05 mg/m^3^) and conditions that may reflect an enhanced response to allergens (e.g., rhinoconjunctivitis; asthma).

The formaldehyde exposure-induced effects associated with allergen sensitization varied depending on the specific mechanistic effect and the experimental animal model. This variability may reflect a lack of consistency in the methods used for sensitization and challenge, or other experimental design differences across studies. Alternatively, these differences might reflect variability in susceptibility to these types of effects across different populations or groups of individuals (e.g., animals of different species, strains, sex, or age). This variable sensitivity of subsets of the population to formaldehyde-induced effects would be consistent with observations of substantial interindividual human variability for several potential health effects. Further, these data suggest that vulnerability to some formaldehyde-induced health effects might be influenced by the exposure history of the individuals, including exposure to known allergens. The mechanism for this amplified response to allergens (and, possibly, nonallergenic antigens) due to formaldehyde exposure, including what airway component(s) formaldehyde may interact with to initiate this particular alteration, remains unknown. Possible explanations include formaldehyde acting as an antigen (capable of directly eliciting an antibody response) or as a hapten (capable of eliciting an antibody response when bound to a larger molecule such as a protein), or formaldehyde-induced chronic inflammation acting as an adjuvant (enhancing immune responses to antigens); however, these speculations have not been examined by directed testing following inhalation exposure. While changes in airway responsiveness could be dependent on stimulation of sensory nerve endings, observations in isolated tracheae by Swiecichowski et al. (1993) and Leikauf (1992) suggest that the amplified response to stimuli is at least partly mediated by interactions with local immuno-modulatory factors. As airway hyperreactivity and other indicators of immunologic sensitization are known to be related to markers (e.g., antibodies) in the blood, some evidence related to these responses are discussed in the subsequent section. Overall, the essential airway immunologic target(s) of inhaled formaldehyde has not yet been identified and verified, thereby presenting a key uncertainty.

Table C-32 Summary of changes in the lower respiratory tract (LRT) as a result of formaldehyde exposure

Endpoint | Study-specific findings from “high or medium” or “low” confidence experiments | | Summary of evidence (exposure duration) | Conclusion
Structural Modification of the Lower Airways
Microvascular Leakage | High or Medium | Human: None | Demonstrated increased leakage from acute exposure ≥6.15 mg/m^3^ in 1 study, which might be mediated by substance P | Moderate ↑ only examined in acute studies
Microvascular Leakage | High or Medium | Animal: Increased in rats (Ito et al., 1996): acute at ≥6.15 mg/m^3^; note: inhibited at 18.45 mg/m^3^ by NK1 receptor antagonist (note: substance P binds NK1R), but not histamine or bradykinin antagonists | Demonstrated increased leakage from acute exposure ≥6.15 mg/m^3^ in 1 study, which might be mediated by substance P | Moderate ↑ only examined in acute studies
Microvascular Leakage | Low | Human: None | One study suggests acute exposure as low as 1.23 mg/m^3^ induces microvascular leakage, although continued exposure appeared to (at least in the near-term) result in less leakage | Moderate ↑ only examined in acute studies
Microvascular Leakage | Low | Animal: Transiently increased in rats (Kimura et al., 2010): acute at ≥1.23 mg/m^3^ (duration-independent); Note: leakage blocked by inhibiting mast cells, but not blocking cyclooxygenases; potential additional mechanistic understanding by injection of formalin into the trachea causing leakage that appeared to be dependent on substance P release after stimulation of C-fiber afferents (Lundberg and Saria, 1983) | One study suggests acute exposure as low as 1.23 mg/m^3^ induces microvascular leakage, although continued exposure appeared to (at least in the near-term) result in less leakage | Moderate ↑ only examined in acute studies
Airway Edema and/or Other Inflammatory Structural Change | High or Medium | Human: None | Bronchial edema in 1 short-term study at 0.31 mg/m^3^ | Moderate ↑ may require higher exposure levels and/or allergen sensitization for pronounced changes
Airway Edema and/or Other Inflammatory Structural Change | High or Medium | Animal: Increased edema in lung bronchi, but not alveoli, without signs of inflammation in lower airways in guinea pigs (Riedel et al., 1996): 5 d at 0.31 mg/m^3^, not 0.16 mg/m^3^ | Bronchial edema in 1 short-term study at 0.31 mg/m^3^ | Moderate ↑ may require higher exposure levels and/or allergen sensitization for pronounced changes
Airway Edema and/or Other Inflammatory Structural Change | Low | Human: None | Airway structural changes with allergen sensitization in 2 species (and, to a lesser extent, without sensitization) with short-term exposure at ≥3 mg/m^3^ | Moderate ↑ may require higher exposure levels and/or allergen sensitization for pronounced changes
Airway Edema and/or Other Inflammatory Structural Change | Low | Animal: Airway structural changes consistent with inflammation (e.g., wall thickening; cell infiltration) in mice (Jung et al., 2007); (Wu et al., 2013; Liu et al., 2011) and in mice and rats sensitized with OVA (Wu et al., 2013 Qiao et al., 2009 Liu et al., 2011), but not in nonsensitized rats (Qiao et al., 2009): all 2–3 wk at ≥3 mg/m^3^ [Note: most studies indicated assessment of bronchial airways] | Airway structural changes with allergen sensitization in 2 species (and, to a lesser extent, without sensitization) with short-term exposure at ≥3 mg/m^3^ | Moderate ↑ may require higher exposure levels and/or allergen sensitization for pronounced changes
Airway/Airway Epithelial Cell Damage | High or Medium | Human: None | N/C in a single mouse subchronic study with i.p. sensitization and up to 2.46 mg/m^3^ exposure, nor in a guinea pig study at 4.18 mg/m^3^ | Slight at higher formaldehyde levels
Airway/Airway Epithelial Cell Damage | High or Medium | Animal: N/C (histology for mouse epithelial cell damage) (Fujimaki et al., 2004b): 12 wk at up to 2.46 mg/m^3^; N/C in histology in guinea pigs (Swiecichowski et al., 1993; Leikauf, 1992): acute at 4.18 mg/m^3^ | N/C in a single mouse subchronic study with i.p. sensitization and up to 2.46 mg/m^3^ exposure, nor in a guinea pig study at 4.18 mg/m^3^ | Slight at higher formaldehyde levels
Airway/Airway Epithelial Cell Damage | Low | Human: None | A single short-term study in mice and another in rats, and indirect evidence from several studies in rats, suggests damage at higher formaldehyde levels (e.g., around 4 mg/m^3^); however, another similar study did not observe effects at 12.3 mg/m^3^ | Slight at higher formaldehyde levels
Airway/Airway Epithelial Cell Damage | Low | Animal: Increased in mice (Jung et al., 2007): 2 wk at ≥6.15 mg/m^3^ and in rats (Aydin et al., 2014): 4 wk at ≥6.15 mg/m^3^; indirect evidence of damage in rats ((Kimura et al., 2010) and (Dallas et al., 1987) and (Sandikci et al., 2009)): 20 hr after acute at 6.15 mg/m^3^ and 1 wk at ≥0. 62 mg/m^3^ (effect magnitude decreased with longer exposures) and 6 wk at 7.38 mg/m^3^ (in adults, not young), and in mice (Abreu et al., 2016): 6–8 hr after acute at 3.7 mg/m^3^, but N/C in rats in another study (Dinsdale et al., 1993): 4 d at 12.3 mg/m^3^ | | Slight at higher formaldehyde levels
LRT Sensory Nerve Activation | High or Medium | Human: None | No evidence to evaluate | Slight levels required for potential activation unknown (note: may involve TRPA1 binding)
LRT Sensory Nerve Activation | High or Medium | Animal: None | No evidence to evaluate | Slight levels required for potential activation unknown (note: may involve TRPA1 binding)
LRT Sensory Nerve Activation | Low | Human: None | A single acute rat study and indirect evidence from potentially related exposures suggest that lower airway sensory nerve afferents may be activated, but the inhaled formaldehyde levels required for such potential activation have not been experimentally demonstrated | Slight levels required for potential activation unknown (note: may involve TRPA1 binding)
LRT Sensory Nerve Activation | Low | Animal: With acute exposure, dose-dependent increase in nerve currents and Cl− release in intact rat trachea (Luo et al., 2013), with supporting evidence of substance P and NK Receptor involvement. Indirectly, increased substance P and CGRP were observed in mouse lung tissue, both were amplified with OVA, and both were dependent on TRP activation (Wu et al., 2013): short term at 3 mg/m^3^. Note: the potential involvement of tracheobronchial reflexes in the pulmonary effects of cigarette smoke constituents, such as nicotine and formalin, may add indirect support | | Slight levels required for potential activation unknown (note: may involve TRPA1 binding)
Immune and Inflammation-Related Changes
[[See Table C-33 for Cellular and Cytokine Response in BAL and LRT tissues]]
Oxidative Stress | High or Medium | Human: Increased exhaled nitric oxide, a noninvasive marker of lower airway inflammation and oxidative stress, in healthy or asthmatic children (Franklin et al., 2000; Flamant-Hulin et al., 2010): unknown duration (likely months to years: classrooms or homes) at 0.04–0.06 mg/m^3^, but not in elderly nursing home patients at lower levels (Bentayeb et al., 2015): unknown duration (likely months to years) at 0.005–0.01 mg/m^3^ | Increased biomarkers (indirect evidence) of oxidative stress in children at ≥0.04 mg/m^3^, but not in elderly individuals at ≤0.01 mg/m^3^ with prolonged (months–years) exposure | Moderate ↑ in children at ≈0.04 mg/m^3^
Oxidative Stress | High or Medium | Animal: None | Increased biomarkers (indirect evidence) of oxidative stress in children at ≥0.04 mg/m^3^, but not in elderly individuals at ≤0.01 mg/m^3^ with prolonged (months–years) exposure | Moderate ↑ in children at ≈0.04 mg/m^3^
Oxidative Stress | Low | Human: None | Multiple studies in two species suggest elevated oxidative stress at ≥1 mg/m^3^ with short-term exposure | Moderate ↑ in children at ≈0.04 mg/m^3^
Oxidative Stress | Low | Animal: in mice: NO and NOS activity increased with 3 d at 3 mg/m^3^ (Yan et al., 2005), GSH levels decreased with 3 wk at ≥0.5 mg/m^3^ (Ye et al., 2013), and increased ROS and/or lipid peroxidation markers with 3 wk at ≥1 mg/m^3^ (Ye et al., 2013) or 2 wk at ≥6.15 mg/m^3^ (Jung et al., 2007), but decreased with acute exposure in 1 study (Matsuoka et al., 2010): 24 hr at 0.12 mg/m^3^; in rats: at ≥12.3 mg/m^3^ increased total oxidant levels and decreased total antioxidant level (Aydin et al., 2014): 4 wk, increased lipid peroxidation markers and protein oxidation markers (Sul et al., 2007): 2 wk, and decreased gamma-glutamyl transpeptidase- indirect evidence (Dinsdale et al., 1993): 4 d | Multiple studies in two species suggest elevated oxidative stress at ≥1 mg/m^3^ with short-term exposure | Moderate ↑ in children at ≈0.04 mg/m^3^
Sustained Inflammation | High or Medium | Human: Increased exhaled nitric oxide, a noninvasive marker of lower airway inflammation and oxidative stress, in healthy or asthmatic children (Franklin et al., 2000; Flamant-Hulin et al., 2010): unknown duration (likely months to years: classrooms or homes) at 0.04–0.06 mg/m^3^ | Immune cell counts are continually elevated in a subchronic mouse study with allergen stimulation at 2.46 mg/m^3^; increased biomarkers (indirect evidence) of lower airway inflammation are observed in children with prolonged exposure. | Moderate may require allergen sensitization in some cases
Sustained Inflammation | High or Medium | Animal: Eosinophils and monocyte counts remain elevated with continued exposure for subchronic duration with allergen (OVA) sensitization (Fujimaki et al., 2004b): 12 wks at 2.46 mg/m^3^ | | Moderate may require allergen sensitization in some cases
Sustained Inflammation | Low | Human: None | BAL cell counts and histologic evidence suggest that inflammation persists for several weeks with short-term exposure, and these effects are amplified by allergen | Moderate may require allergen sensitization in some cases
Sustained Inflammation | Low | Animal: Immune cell counts were increased with short term exposure in several studies at ≥0.5 mg/m^3^ (see Table C-33); histological evidence of inflammation without epithelial damage was noted in short-term studies, typically at higher concentrations, which were amplified by allergen (e.g., ≥3 mg/m^3^, (Wu et al., 2013; Kimura et al., 2010)). | BAL cell counts and histologic evidence suggest that inflammation persists for several weeks with short-term exposure, and these effects are amplified by allergen | Moderate may require allergen sensitization in some cases
Immune Function (inferred from LRT infections) | High or Medium | Human: Increased LRT infections in infants (Roda et al., 2011): 32–41% increase in incidence per 0.0124 mg/m^3^ increase in formaldehyde (LOD: 0.008 mg/m^3^); ≈1-year exposure at 0.020 mg/m^3^ (median) | Indirect evidence in a single study of infants exposed to a median of 0.020 mg/m^3^ that observed an association between exposure and increased infections. One acute mouse study also provided indirect support for an increased likelihood of respiratory infections. | Moderate supports an increased propensity for LRT infections, particularly during development
Immune Function (inferred from LRT infections) | High or Medium | Animal: Decreased antibacterial activity in mice (Jakab, 1992): acute at 1.23 mg/m^3^, noting that this finding appeared to be particularly sensitive to the pattern of formaldehyde exposure | | Moderate supports an increased propensity for LRT infections, particularly during development
Immune Function (inferred from LRT infections) | Low | Human: Increased emergency room visits for episodes including LRT infections (Rumchev et al., 2002): children aged 6–36 mos with mean levels of 0.028–0.030 (maximum 0.12–0.22) mg/m^3^ | Direct and indirect evidence of impaired LRT immune function in children and in a short-term rat study, respectively | Moderate supports an increased propensity for LRT infections, particularly during development
Immune Function (inferred from LRT infections) | Low | Animal: Decreased expression of immune-related genes in rat lung (Sul et al., 2007), specifically HSP701a (may be involved in antigen presentation), complement 4 binding protein (may bind necrotic or apoptotic cells for cleanup), and Fc portion of IgGiii (may be involved in leukocyte activation): 2 wk at ≥6.15 mg/m^3^ | Direct and indirect evidence of impaired LRT immune function in children and in a short-term rat study, respectively | Moderate supports an increased propensity for LRT infections, particularly during development
Changes in pulmonary function with challenge (e.g., with bronchoconstrictors and/or allergens) (Note: unprovoked responses are not included) | High or Medium | Human: None | Acute and short-term studies in two animal species demonstrate that formaldehyde increases responsiveness to allergens and bronchoconstrictors, particularly with prior sensitization, at levels as low as 0.31 mg/m^3^ | Robust ↑ Hyperresponsive airways^a^ (↑ effects with allergen)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictors and/or allergens) (Note: unprovoked responses are not included) | High or Medium | Animal: [allergen challenge]: With ovalbumin [OVA] sensitization, increased airway obstruction in guinea pigs (Riedel et al., 1996): short-term at 0.31 mg/m^3^ and increased reactivity in mice (Larsen et al., 2013): acute at ≈5–7 mg/m^3^ in humid or dry environments; [acetylcholine challenge]: Increased airway resistance and reactivity in guinea pigs (Swiecichowski et al., 1993; Leikauf, 1992): acute at 1.23 mg/m^3^ | | Robust ↑ Hyperresponsive airways^a^ (↑ effects with allergen)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictors and/or allergens) (Note: unprovoked responses are not included) | Low | Human: [histamine challenge]: Hyperreactive airways with prolonged exposure (Górski and Krakowiak, 1991): ≥1 year at ≤0.5 mg/m^3^, but N/C after acute exposure (Krakowiak et al., 1998): 2 hr at 0.5 mg/m^3^; [allergen challenge]: hypersensitivity with acute exposure when exposure was restricted to mouth breathing in allergic asthmatics with a large allergen (mite) (Casset et al., 2006): ≤1 hr at 0.1 mg/m^3^, but N/C after acute oronasal (normal) exposure in allergic asthmatics using a different allergen (pollen), including a test of methacholine (MCh) responsiveness 8 hr after allergen exposure (Ezratty et al., 2007): 1 hr at 0.5 mg/m^3^ | Suggestive evidence of increases with prolonged exposure, and possibly acute mouth-breathing exposure when challenged with specific allergens, but not acute exposure alone, to ≤0.5 mg/m^3^ in human adults; also, increased at ≥3 mg/m^3^ in short-term or acute studies across three species, particularly with prior sensitization. | Robust ↑ Hyperresponsive airways^a^ (↑ effects with allergen)
Changes in pulmonary function with challenge (e.g., with bronchoconstrictors and/or allergens) (Note: unprovoked responses are not included) | | Animal: [MCh challenge]: Hyperresponsive airways (increased reactivity and sensitivity) noted with FA alone in mice and rats (Wu et al., 2013 Qiao et al., 2009; Liu et al., 2011): short-term at ≥3 mg/m^3^, and in monkeys (Biagini et al., 1989): acute at 3.1 mg/m^3^; in mice and rats, this response was amplified with OVA sensitization; Note: TRP antagonists reduced the hyperresponsiveness in mice (Wu et al., 2013)

a As the challenge stimuli used in the formaldehyde studies included allergens as well as nonimmunological stimuli, and because most experiments did not attempt to delineate the specifics of the functional changes, “airway hyperresponsiveness” or “hyperresponsive airways” encompasses any of a range of possible airway features: hyperreactivity (exaggerated response), hypersensitivity (lower dose to elicit response), altered ventilatory parameters (e.g., maximal response; resistance), recovery (longevity of response), or others.

Table C-33 Summary of changes in LRT cell counts and immune factors as a result of formaldehyde exposure

Endpoint(s) | | | No changes observed (high or medium confidence experiments are bolded) | | Significant^a^ increases or decreases (high or medium confidence experiments are bolded) | | Summary conclusion Clarifying notes and exposure duration
Endpoint(s) | | | Duration (species) | Concentration(s) [allergen stimulus] (study) | Duration (species) | Concentration(s) [allergen stimulus] (study) | Summary conclusion Clarifying notes and exposure duration
| Total WBCs (or Total Inflammatory Cells) | | Acute (g pigs); Acute (humans); Acute (mice); Acute (mice) | 0.13–0.31 mg/m^3^ [−OVA] ( Riedel et al., 1996; 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007); 0.5–6.2 mg/m^3^ [−OVA] (Larsen et al., 2013); 0.25–3.7 mg/m^3^ [−OVA] (Abreu et al., 2016) | Subchronic (mice); Short term (mice); Short term (mice); Short term (mice); Short term (rats) | ↑ 2.5 mg/m^3^ [+ OVA] (Fujimaki et al., 2004b); ↑ 12.3 mg/m^3^ [−OVA] (Kim et al., 2013a); total BAL cells; ↑ 12.3 mg/m^3^ [−OVA] (Jung et al., 2007); ↑ 3 mg/m^3^ [± OVA] (Wu et al., 2013); ↑ 0.5–3.1 mg/m^3^ [+ OVA] (Qiao et al., 2009) | Moderate ↑ short-term ≥0.5 mg/m^3^; amplifies allergen effect
| Granulocytes | Neutrophils | Subchronic (mice); Acute (g pigs); Short term (mice); Acute (humans) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b); 4.2 mg/m3 [−OVA] (Swiecichowski et al., 1993); 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Short term (mice); Acute (rats) | ↑ 3 mg/m^3^ [+ OVA] (Wu et al., 2013); Acute (rats) ↑ 6.2 mg/m^3^ [−OVA] (Kimura et al., 2010) | Slight ↑ amplifies allergen response at >3 mg/m^3^ ([underlined: short-term])
| Granulocytes | Eosinophils | Acute (humans); Acute (humans); Acute (rats) | (trend ↑) 0.1 mg/m^3^[+ Der^b^ f] (Casset et al., 2007); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007); 6.2 mg/m^3^ [−OVA] (Kimura et al., 2010) | Subchronic (mice); Short term (mice); Short term (mice); Short term (mice); Short term (rats) | ↑ 2.5 mg/m^3^ [+ OVA] (Fujimaki et al., 2004b); ↑ 12.3 mg/m^3^ [−OVA] (Jung et al., 2007); ↑ 0.5–3 mg/m^3^ [± OVA] (Liu et al., 2011); ↑ 3 mg/m^3^ [± OVA] (Wu et al., 2013); ↑ infer^1^ >12.3 mg/m^3^ [+ Der f] (Sadakane et al., 2002); ↑ 0.5–3.1 mg/m^3^ [+ OVA] (Qiao et al., 2009) | Moderate ↑ short-term ≥0.5 mg/m^3^; amplifies allergen effect
| Lymphocytes | All | Subchronic (mice); Short term (mice); Short term (mice); Acute (humans) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b); 6.2–12.3 mg/m^3^ [−OVA] (Kim et al., 2013a); 12.3 mg/m^3^ [−OVA] (Jung et al., 2007); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Short term (mice) | ↑ 3 [−OVA] mg/m^3^ (Wu et al., 2013) | Indeterminate suggests total number unchanged
| Lymphocytes | B Cells | Acute (g pigs); Short term (mice); Short term (mice | 4.2 mg/m^3^ [−OVA] (Swiecichowski et al., 1993); 6.2–12.3 mg/m^3^ [−OVA] (Kim et al., 2013a); (trend ↓) 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | | | Indeterminate allergen stimulus unstudied
| Lymphocytes | T Cells (CD4^+^) | Short term (mice); Short term (mice) | 6.2–12.3 mg/m^3^ [−OVA] (Kim et al., 2013a); (trend ↑) 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | Short term (rats) | ↑ (adults) 7.4 mg/m^3^ [−OVA] (Sandikci et al., 2007b) | Indeterminate allergen stimulus unstudied
| Lymphocytes | T Cells (CD8^+^) | Short term (mice) | 6.2–12.3 mg/m^3^ [−OVA] (Kim et al., 2013a) | Short term (rats); Short term (mice) | ↑ (adults) 7.4 mg/m^3^ [−OVA] (Sandikci et al., 2007b); ↑ (slight) 12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | Slight↑ short-term >7 mg/m^3^, allergen stimulus unstudied
| Lymphocytes | NK Cells | | | Short term (mice) | ↓ 12.3 mg/m^3^ [−OVA] (Kim et al., 2013a) | Indeterminate
| Monocytes | | Acute (g pigs); Acute (humans); Acute (rats) | 4.2 mg/m^3^ [−OVA] (Swiecichowski et al., 1993); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007); 6.2 mg/m^3^ [−OVA] (Kimura et al., 2010) | Subchronic (mice) | ↑ 2.5 mg/m^3^ [+ OVA] (Fujimaki et al., 2004b) | Slight↑ long-term ≥2.5 mg/m^3^ amplifies allergen effect
Mast Cells | | | Acute (g pigs) | 4.2 mg/m^3^ [−OVA] (Swiecichowski et al., 1993) | | | Indeterminate
Secreted factors andimmune markers | Primarily Th1-related | TNF-α and GM-CSF | Subchronic (mice); Acute (humans); Acute (mice) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007); 0.25–3.7 mg/m^3^ [−OVA] (Abreu et al., 2016) | | | Indeterminate suggests unchanged or highly variable
Secreted factors andimmune markers | Primarily Th1-related | IFN-γ | Short term (mice); Short term (mice); Acute (humans) | 0.5–3 mg/m^3^ [± OVA] (Liu et al., 2011); 3 mg/m3 [± OVA] (Wu et al., 2013); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Short term (mice); Short term (rats) | ↓ 6.2–12.3 mg/m^3^ [−OVA] (Kim et al., 2013a); ↑ 3.1 mg/m^3^ [−OVA] (Qiao et al., 2009) | Indeterminate suggests unchanged or highly variable
Secreted factors andimmune markers | Primarily Th1-related | IL-1 (IL-1β in animals) | Acute (humans); Acute (mice) | 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007); 0.25–3.7 mg/m^3^ [−OVA] (Abreu et al., 2016) | Subchronic (mice); Short term (mice); Short term (mice) | ↓ 2.5 mg/m^3^ [+ OVA] (Fujimaki et al., 2004b); ↑ 3 mg/m3 [−OVA] (Wu et al., 2013); ↑ 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | Indeterminate suggests unchanged or highly variable
Secreted factors andimmune markers | Primarily Th2-related | IL-4 | Short term (mice); Acute (humans) | infer^a^ >12.3 mg/m^3^ [± Der f] (Sadakane et al., 2002); 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Short term (mice); Short term (mice); Short term (mice); Short term (mice); Short term (rats) | ↑ 1–3 mg/m^3^ [−OVA] (Lu et al., 2005); ↑ 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007); ↑ 0.5–3 [+ OVA] or 3 [−OVA] mg/m^3^ (Liu et al., 2011); ↑ 3 mg/m^3^ [± OVA] (Wu et al., 2013); ↑ 0.5–3.1 mg/m^3^ [+ OVA]; ↓ 3.1 mg/m^3^ [−OVA] (Qiao et al., 2009) | Slight↑ IL-4 at ≥0.5 mg/m^3^ and IL-5 at ≥6.15 mg/m^3^, short-term and likely amplifying allergen effects
Secreted factors andimmune markers | Primarily Th2-related | IL-5 | Acute (humans) | 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Short term (mice); Short term (mice) | ↑ 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007); ↑ infer^a^ >12.3 mg/m^3^ [+ Der f] (Sadakane et al., 2002) | Slight↑ IL-4 at ≥0.5 mg/m^3^ and IL-5 at ≥6.15 mg/m^3^, short-term and likely amplifying allergen effects
Secreted factors andimmune markers | Primarily Th2-related | IL-10 | Acute (humans) | 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | | | Indeterminate
Secreted factors andimmune markers | Primarily Th2-related | IL-6 | Subchronic (mice); Acute (mice) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b); 0.25–3.7 mg/m^3^ [−OVA] (Abreu et al., 2016) | Short term (mice) | ↑ 0.5–3 [+ OVA] or 3 [−OVA] mg/m^3^ (Liu et al., 2011) | Indeterminate
Secreted factors andimmune markers | Primarily Th2-related | IL-13 | Short term (mice) | 6.2–12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | | | Indeterminate
Secreted factors andimmune markers | NK cell factors | IL-2R | | | Short term (mice) | ↓ 6.2–12.3 mg/m^3^ (Kim et al., 2013a) | Indeterminate
Secreted factors andimmune markers | NK cell factors | Perforin | | | Short term (mice) | ↓ 6.2–12.3 mg/m^3^ (Kim et al., 2013a) | Indeterminate
Secreted factors andimmune markers | Eosinophil | RANTES | | | Short term (mice) | ↑ infer^a^ >12.3 mg/m^3^ [± Der f] (Sadakane et al., 2002) | Slight↑ chemoattractants relevant to eosinophil recruitment with [underlined: short-term] exposure
Secreted factors andimmune markers | Eosinophil | ICAM and CCR3 | | | Short term (mice) | ↑ (indirect^b^) 12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | Slight↑ chemoattractants relevant to eosinophil recruitment with [underlined: short-term] exposure
Secreted factors andimmune markers | Eosinophil | Eotaxin | Subchronic (mice); Acute (humans) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b)^3^; 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Short term (mice); ↑ (indirect^b^) 12.3 mg/m^3^ [−OVA] (Jung et al., 2007) | | Slight↑ chemoattractants relevant to eosinophil recruitment with [underlined: short-term] exposure
Secreted factors andimmune markers | Eosinophil | ECP | Acute (humans) | 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Acute (humans) | ↑ 0.1 mg/m^3^ [+ Der f] (Casset et al., 2007) | Slight↑ chemoattractants relevant to eosinophil recruitment with [underlined: short-term] exposure
Secreted factors andimmune markers | Eosinophil | MIP-1α | Subchronic (mice) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b)^3^ | | | Slight↑ chemoattractants relevant to eosinophil recruitment with [underlined: short-term] exposure
Secreted factors andimmune markers | Other | IL-8 | Acute (humans) | 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | Acute (in vitro) | ↑ 1.23 mg/m^3^ (Rager et al., 2011) | Indeterminate
Secreted factors andimmune markers | Other | MCP-1 | Subchronic (mice); Acute (humans) | 0.1–2.5 mg/m^3^ [± OVA] (Fujimaki et al., 2004b)^3^; 0.5 mg/m^3^ [+ pollen] (Ezratty et al., 2007) | | | Indeterminate

Der f: Dermatophagoides farina (house dust mite); OVA: ovalbumin (major protein of chicken egg whites); both are immunogenic materials used to stimulate an allergic response.

Gray box = no data meeting the inclusion criteria were available.

Notes: Two studies with evidence that may inform the potential for formaldehyde exposure-induced inflammatory changes in the LRT are not captured in these tables, specifically a proteomics analysis of the BAL fluid after short-term exposure at ≥2.46 mg/m^3^ (Ahn et al., 2010) and an miRNA microarray study of gaseous paraformaldehyde exposure in a human lung cancer cell line with acute exposure to 1.23 mg/m^3^ (Rager et al., 2011). Swiecichowski et al. (1993) may include information from an earlier study interpreted to have been conducted in the same cohort of guinea pigs (Leikauf, 1992).

a Primarily, this reflects reporting of a statistically significant change; in rare instances where a p value was not given, changes are indicated if the authors discussed the change as a significant effect.

b Reported as 0.5% formaldehyde solution; concentration assumed to be >12.3 mg/m^3^ (Sadakane et al., 2002).

c Gene expression levels.

d These factors were not present at detectable levels regardless of treatment.

### C.7.3 Synthesis of Changes in the Blood and Lymphoid Organs

Although this mechanistic evaluation is focused on mechanisms underlying respiratory health effects, these effects can be influenced by changes in nonrespiratory tissue compartments, most notably the blood and lymphoid organs. The direction, magnitude and type of immune responses observed in the blood should not be assumed to represent immunological changes occurring in the airways, as responses can differ. The nonrespiratory changes most likely relevant to respiratory system health effects are immune-related changes because these could induce extrapulmonary signals (e.g., cellular; secreted factors) to travel through the blood to perfused regions of the respiratory tract. This section emphasizes changes in exposed humans, unlike the emphasis on experimental animal studies in the URT and LRT sections, because blood sampling in humans is more convenient than sampling from respiratory tissue compartments; thus, more human data are available for changes in the blood (see Tables C-34 and C-35).

A number of studies, across different human and animal populations, spanning an array of formaldehyde exposure scenarios, have reported changes in blood cell counts and other secreted factors (see Tables C-34 and C-35). Although some of the specific changes vary across studies, taken together, the data provide robust evidence of an association between formaldehyde exposure and hematological effects. Although additional studies clarifying inconsistencies across the studies would be informative, several tentative patterns could be discerned. Interestingly, looking at the picture as a whole (see Figures C-23 and C-24), the direction of some changes noted in the blood of individuals exposed to formaldehyde are contrary to the cellular changes noted in the respiratory tract. For example, data suggest (slight) or support (moderate) that total cells, neutrophils, and CD8^+^ T cells are increased in the respiratory tract by formaldehyde exposure, while these same cells appear to be decreased in the blood. One potential explanation for this difference could involve recruitment of particular subsets of immuno-responsive cells from the circulation to the irritated and inflamed respiratory tract, as is observed with viral infections of the respiratory system (Levandowski et al., 1986); however, none of the identified human studies report data from both tissue compartments, and the animal data do not address such a hypothesis. It is plausible that this pattern could reflect species differences (i.e., LRT data are mostly from animal studies), but this possibility is considered unlikely given the blood data. As with investigations of the airways, very few studies tested mechanistic hypotheses for how formaldehyde exposure could affect blood immune cell counts. Despite this lack of information and variability in responses, the available data support a conclusion that formaldehyde exposure can modify immune system function in the blood across a range of concentrations and exposure durations.

One of the most consistent cellular changes observed across studies was a decrease in the total number of white blood cells (WBCs). This is a nonspecific finding, as WBCs encompass a spectrum of functional phenotypes, and this change may be driven by decreases in only one or several subpopulations. When looking more specifically at the WBCs, moderate evidence of CD8^+^ T cell decreases following formaldehyde exposure is provided by several studies, together with a corresponding increase in the ratio of CD4^+^/CD8^+^ T cells (see Table C-35). As mentioned previously, CD8^+^ T cells comprise a heterogeneous cell population, which complicates interpretations regarding the potential impact of decreased numbers in peripheral blood. Depending on the specific stimuli, stimulated CD8^+^ T cells can produce interferon-γ (IFN-γ) and inhibit production of IL-4 and immunoglobulin (i.e., IgE) responses (Holmes et al., 1997), or their phenotype can be driven towards production of excess IL-4, a situation hypothesized to be associated with atopic asthma (Lourenço et al., 2016). Moderate evidence provides support for increases in blood IL-4 (which was similarly increased in the LRT) and decreases in IFN-γ after formaldehyde exposure. A more complete understanding of the phenotype of the depleted CD8^+^ T cells would be informative to ascertain whether these changes are related to the profile of secreted factors observed in the blood after formaldehyde exposure.^18^

Moderate evidence also indicates that formaldehyde exposure alters the number or percentage of B cells in the circulation. These cells produce antibodies upon stimulation with antigen (e.g., allergens) and contribute to airway hyperresponsiveness (Hamelmann et al., 1997). While this finding, along with slight evidence of increased antigenic markers, suggests potential for alteration of the adaptive immune response as a result of formaldehyde exposure, this observation alone is insufficient to indicate functional changes such as exposure-induced differences in clonal expansion and differentiation to antibody-producing cells, evidence of which would support a more convincing biological relationship.

Slight evidence suggests that neutrophils are also decreased in the blood by formaldehyde exposure. This could plausibly be explained by the suggestive (slight) findings of decreased lymphocyte and neutrophil chemoattractants in the blood and increased levels in the airways (possibly attracting blood neutrophils), suggesting that a gradient of these factors across tissue compartments may be induced and maintained as a result of formaldehyde exposure and, perhaps, sustained inflammation.

Finally, although variable across studies, several lines of evidence suggest a pattern of immune cell effects related to formaldehyde concentration, with stimulation at lower formaldehyde exposure levels and decreases at higher levels. This included changes in total T cells, NK cells, and IL-10 (and, perhaps, TNF-α). A complex relationship exists between IL-10, NK cells, and subsets of CD4^+^ T cells (e.g., Th1 and Th2 cells), which direct the type of antibody responses; however, the specifics of this suggestive (slight) association with formaldehyde exposure remain to be elucidated. Many of these observations would benefit from additional, more specific studies on WBCs.

Red blood cell (RBC) counts were decreased in both human and animal studies (moderate evidence), generally at formaldehyde concentrations above 0.5 mg/m^3^. Slight data exist to suggest that platelets may also be decreased, which could plausibly be related to the single, low confidence animal study that reported increased megakaryocytes (cells that produce platelets) in the bone marrow (Zhang et al., 2013). The relevance of these changes to respiratory system health effects is unknown. It is plausible that sustained increases in oxidative stress (which has been observed in the blood and, to a lesser extent, other lymphoid tissues) and/or other soluble factors in the blood resulting from airway inflammation could affect the viability of circulating erythrocytes and immune cells or the circulating precursors for these cells; however, no evidence exists to substantiate this hypothesis. An increased level of the circulating stress hormone, corticosterone (the major animal glucocorticoid; in humans, it is cortisol), with short-term, but not acute, formaldehyde exposure is also suggested by slight data. Persistent increases in circulating glucocorticoids can also negatively impact the function and health of circulating immune cells, causing immunosuppression of most cell types (O’Connor et al., 2000). However, these potential linkages have not been examined.

As with findings for WBC changes, antibody, or immunoglobulin (Ig), responses resulting from formaldehyde exposure are consistently altered, although the specific changes observed across studies provide a mixed picture (see Table C-34). Much of the moderate evidence is based on animal sensitization models using the protein allergen ovalbumin, although the human data also indicate changes after exposure. In general, the variable evidence of formaldehyde-induced modification of humoral immunity in humans demonstrates different patterns of results depending on the population (e.g., children vs. adults), the duration of exposure, and the specific Ig measure (e.g., Ig isotype) across studies. The animal studies consistently report amplified responses with allergen stimulation and/or sensitization, although the pattern and magnitude of these effects appears to vary depending on the type of allergen and the sensitization protocol used. The Igs most relevant to the blood and respiratory tract are IgA (IgA1 and IgA2), IgE, IgM, and IgG (IgG1, IgG2, and IgG3; also, IgG4 in humans). No changes of note in IgA or IgM were identified across the available studies. Slight data suggest that formaldehyde exposure may cause elevated levels of IgE antibodies in certain exposure scenarios, including in exposed children; however, this finding should be interpreted with caution, as comparable studies did not observe effects, and explanations for this inconsistency are not available. IgEs are implicated in allergic hypersensitivity responses of the airways (Hamelmann et al., 1999), although they may not be essential for all hypersensitivity-related responses (e.g., intrinsic [nonallergic] asthma occurs in one-third of all adult patients; (Knudsen et al., 2009). Despite the variability in models, several of the available studies consistently identified changes in antibodies of the IgG class (moderate evidence), including increases in IgGs specific to formaldehyde or antigens (e.g., allergens) to which the subjects had previously been exposed. IgGs are the most prevalent Ig in the serum of humans, and they are the only Ig that can be transferred to neonatal/infant circulation (i.e., by crossing the placenta; through breast milk in animals) to influence immunity in offspring (Van de Perre, 2003). None of the included studies examined antibody titers or transferred immunity with developmental formaldehyde exposure (note: not informative studies from one lab: (Silva Ibrahim et al., 2015; Maiellaro et al., 2014) reported immune-related effects of gestational formaldehyde exposure). While IgEs are most commonly associated with sensitization-related airway hyperresponsiveness to allergens, subclasses of IgGs also contribute to allergic responses; however, their exact role in the pathophysiology of airway disorders remains unclear [(Williams et al., 2012; Hofmaier et al., 2014; Bogaert et al., 2009)]. Overall, although a body of evidence indicates changes in antibody-mediated responses after formaldehyde exposure, particularly in regard to IgGs, an explanation for the variable pattern of changes in Igs (e.g., to formaldehyde alone or with coexposure to different types of antigens by specific Ig subclasses) does not exist, and the likely consequences of these changes are unknown.

Table C-34 Summary of changes in the blood and lymphoid organs as a result of formaldehyde exposure

Endpoint | Study-specific findings from “high or medium” or “low” confidence experiments | | Summary of evidence ([underlined: exposure duration]) | Conclusion
Formaldehyde-Induced Antibody Response in the Blood
Total IgE | High or Medium | Human: None | No changes in a [underlined: subchronic] mouse study at ≤2.46 mg/m^3^ | Moderate; Altered antibody responses (basis below); [underlined: Total]; Moderate↓: IgG [naïve subjects] Slight ↑: IgE [3 mg/m^3^] IgA [6 mg/m^3^] Indeterminate: IgM [mixed]; [underlined: FA-specific]; Moderate ↑: IgG [long-term] Slight ↑: IgE [children; long-term] Indeterminate: IgM or IgA; [underlined: Antigen-specific]; Moderate ↑: IgG [inhaled antigen] Slight ↑: IgE [certain scenarios]; Indeterminate: IgM or IgA
Total IgE | High or Medium | Animal: No evidence suggesting changes (Fujimaki et al., 2004b): subchronic ≤2.46 mg/m^3^ | No changes in a [underlined: subchronic] mouse study at ≤2.46 mg/m^3^
Total IgE | Low | Human: No evidence suggesting changes (Wantke et al., 1996b; Wantke et al., 2000; Palczynski et al., 1999; Ohmichi et al., 2006; Erdei et al., 2003): short-term ≤1.8 mg/m^3^ (duration in Erdei unknown) | Suggestive evidence of increased IgE in 2 [underlined: short-term] formalin studies in mice at ≥3 mg/m^3^, but no evidence for changes in mice or humans at <2 mg/m^3^
Total IgE | Low | Animal: Evidence of increases in mice, which were increased further by OVA (Wu et al., 2013; Jung et al., 2007): short-term ≥3 mg/m^3^; evidence of no changes in mice by FA alone (Kim et al., 2013a; Gu et al., 2008), although FA exacerbated HDM-induced IgE (Kim et al., 2013a): short-term 0.12–1.2 mg/m^3^ | Suggestive evidence of increased IgE in 2 [underlined: short-term] formalin studies in mice at ≥3 mg/m^3^, but no evidence for changes in mice or humans at <2 mg/m^3^
Formaldehyde (FA)-Specific IgE | High or Medium | Human: Elevated in one study of children (Wantke et al., 1996a): years (assumed) at ≈0.06 compared to ≈0.03 mg/m^3^ (unrelated to symptoms); N/C in adults (Kim et al., 1999): 4 years at 3.74 mg/m^3^ | Increased in a single [underlined: long-term] study of children at <0.1 mg/m^3^; N/C in a single long-term study of adults at 3.74 mg/m^3^
Formaldehyde (FA)-Specific IgE | High or Medium | Animal: None | Increased in a single [underlined: long-term] study of children at <0.1 mg/m^3^; N/C in a single long-term study of adults at 3.74 mg/m^3^
Formaldehyde (FA)-Specific IgE | Low | Human: No evidence of changes across multiple studies in adults (Zhou et al., 2005; Wantke et al., 1996b; Thrasher et al., 1987; Ohmichi et al., 2006; Kim et al., 1999; Górski and Krakowiak, 1991): short-term (weeks) or long-term (years) at ≈0.1–3.74 mg/m^3^; unclear in 2 long-term adult studies in which a small proportion of subjects did have FA-IgE (Thrasher et al., 1990; Dykewicz et al., 1991); one study noted slight increases with longer exposure (Wantke et al., 2000): 10 wk, not 5 wk, at 0.265 mg/m^3^ | No clear evidence of changes across multiple [underlined: short-term and long-term] studies in adults at ≤3.74 mg/m^3^; no studies in children
Formaldehyde (FA)-Specific IgE | Low | Animal: Isotype unspecified- no change in guinea pigs with acute challenge (Lee et al., 1984) at 2.5 or 4.9 mg/m^3^ after short term exposure to 7.4 or 12.3 mg/m^3^ (note: no measures without formaldehyde) | No clear evidence of changes across multiple [underlined: short-term and long-term] studies in adults at ≤3.74 mg/m^3^; no studies in children
Antigen-Specific IgE (does not include FA-specific Ig) | High or Medium | Human: None | N/C in a single [underlined: subchronic] study with i.p. sensitization
Antigen-Specific IgE (does not include FA-specific Ig) | High or Medium | Animal: N/C in OVA-IgE (Fujimaki et al., 2004b): 12 wks at 0.1–2.46 mg/m^3^ (OVA i.p.) | N/C in a single [underlined: subchronic] study with i.p. sensitization
Antigen-Specific IgE (does not include FA-specific Ig) | Low | Human: None | Two mouse studies suggest formaldehyde can increase IgE specific to antigen at ≈≥1 mg/m^3^, but this appears to be highly situational (e.g., [underlined: dependent on duration and periodicity] of formaldehyde exposure, and antigen type and administration route)
Antigen-Specific IgE (does not include FA-specific Ig) | Low | Animal: Increased OVA-specific IgE in mice in 2 studies―(Tarkowski and Gorski, 1995; Gu et al., 2008): 10 d at 2 mg/m^3^ (but not 1 d/wk for 7 wk, or when OVA sensitization i.p.) and 5 wk at 0.98 mg/m^3^ with i.p. OVA (but not ≤4 wk), respectively; however, N/C in mice in 3 studies: (Wu et al., 2013): 4 wk at 3 mg/m^3^ (s.c. OVA sensitization), (Kim et al., 2013b): 0.2–1.23 mg/m^3^ for 4 wk (dermal house dust mite, HDM, sensitization), and (Sadakane et al., 2002): 4 wk at 0.5% (i.p. Der f sensitization)
Total IgG | High or Medium | Human: Decreased in a single study of exposed workers (Aydın et al., 2013): 7 year at 0.264 mg/m^3^ | A single study in adult workers and another in male rats showed decreased IgG at 0.264 or ≥6.15 mg/m^3^ with [underlined: long-term] or [underlined: short-term] exposure, but subclass not examined
Total IgG | High or Medium | Animal: Decreased total IgG in rats (Sapmaz et al., 2015): short-term at ≥6.15 mg/m^3^ | A single study in adult workers and another in male rats showed decreased IgG at 0.264 or ≥6.15 mg/m^3^ with [underlined: long-term] or [underlined: short-term] exposure, but subclass not examined
Total IgG | Low | Human: N/C in children at ≈0.007–0.07 mg/m^3^ (Erdei et al., 2003): unknown duration (likely months-years) | Suggestive evidence based on increased IgG1 in 2 [underlined: short-term] mouse studies, but a third mouse study and a human study did not observe effects at <1 mg/m^3^
Total IgG | Low | Animal: IgG1 (N/C in IgG2a) increased by FA alone, whereas FA exacerbated IgG2a (N/C in IgG1) in atopic-prone mice (Kim et al., 2013b): short-term 0.25, not 1.2 mg/m^3^; increased IgG1 and IgG3, but decreased IgG2a and 2b, in C57 mice (Jung et al., 2007) short-term ≥6.15 mg/m^3^; N/C in IgG Balb/c mice (Gu et al., 2008): short-term <1 mg/m^3^ | Suggestive evidence based on increased IgG1 in 2 [underlined: short-term] mouse studies, but a third mouse study and a human study did not observe effects at <1 mg/m^3^
FA-Specific IgG | High or Medium | Human: Slight (<10%) increase in a single study of adults (Kim et al., 1999): years at 3.74 mg/m^3^ | Slightly increased in a single [underlined: long-term] study of adults at 3.74 mg/m^3^; no studies in children
FA-Specific IgG | High or Medium | Animal: None | Slightly increased in a single [underlined: long-term] study of adults at 3.74 mg/m^3^; no studies in children
FA-Specific IgG | Low | Human: Increased in two studies (Thrasher et al., 1987; Thrasher et al., 1990) and unclear in 1 study in which 5/55 subjects did have FA-IgG (Dykewicz et al., 1991): [all 3 studies] years at <0.1–<1.0 mg/m^3^; N/C in one study (Wantke et al., 2000): short-term at 0.265 mg/m^3^ | Suggestive of slight increases in adults with [underlined: long-term] exposure at <1 mg/m^3^, but not with short-term exposure at higher levels; no studies in children
FA-Specific IgG | Low | Animal: Isotype unspecified―no change in guinea pigs with acute challenge (Lee et al., 1984) at 2.5 or 4.9 mg/m^3^ after short term exposure to 7.4 or 12.3 mg/m^3^ (note: no measures without formaldehyde) | Suggestive of slight increases in adults with [underlined: long-term] exposure at <1 mg/m^3^, but not with short-term exposure at higher levels; no studies in children
Antigen-Specific IgG (does not include FA-specific Ig) | High or Medium | Human: None | Increased OVA-IgG1 in 1 [underlined: short-term] study in guinea pigs at 0.31 mg/m^3^ with inhaled allergen, but not a longer mouse study using injected allergen
Antigen-Specific IgG (does not include FA-specific Ig) | High or Medium | Animal: Increased OVA-specific IgG1 in guinea pigs (Riedel et al., 1996): 5 d at 0.31 mg/m^3^ (inhaled OVA); questionable decrease (no dose-response) in OVA-IgG1 and OVA-IgG3 in mice (Fujimaki et al., 2004b): 12 wks at 0.49, but not 2.46 mg/m^3^ (OVA i.p.; N/C in OVA-IgG2) | Increased OVA-IgG1 in 1 [underlined: short-term] study in guinea pigs at 0.31 mg/m^3^ with inhaled allergen, but not a longer mouse study using injected allergen
Antigen-Specific IgG (does not include FA-specific Ig) | Low | Human: Increased IgG against 2 bacterial pathogens by linear regression in 3^rd^ grade children with respiratory complaints (Erdei et al., 2003): <0.1 mg/m^3^, unknown duration (likely years, home measures) | 1 [underlined: long-term] study suggests increased IgG sensitization to an airway antigen by FA in children; multiple studies in mice and rats suggest that IgG sensitization does not occur when antigen sensitization occurs by injection
Antigen-Specific IgG (does not include FA-specific Ig) | Low | Animal: N/C in OVA-IgG or Der f-IgG1 in mice (Wu et al., 2013; Sadakane et al., 2002; Gu et al., 2008): up to 5 wk at 0.123–3 mg/m^3^ or higher; N/C in IgG specific to vaccine antigens in rats (Holmstrom, 1989): 22 months at 15.5 mg/m^3^. In all cases, s.c. or i.p. sensitization
Total IgM or IgA | High or Medium | Human: Decreased IgM, N/C in IgA, in a study of exposed workers (Aydın et al., 2013): 7 year at 0.26 mg/m^3^ | IgM, but not IgA, decreased in a single study in adult workers at 0.26 mg/m^3^ with [underlined: long-term] exposure
Total IgM or IgA | High or Medium | Animal: Increased total IgM and IgA in rats (Sapmaz et al., 2015): short-term at ≥6.15 mg/m^3^ | IgM, but not IgA, decreased in a single study in adult workers at 0.26 mg/m^3^ with [underlined: long-term] exposure
Total IgM or IgA | Low | Human: No evidence of IgA or IgM changes (Erdei et al., 2003): duration unknown ≤0.1 mg/m^3^ | IgA increased in 1 [underlined: short-term] study at >6 mg/m^3^; N/C in IgM in 2 studies
Total IgM or IgA | Low | Animal: Increased IgA and N/C in IgM in C57 mice (Jung et al., 2007): short-term ≥6.15 mg/m^3^ | IgA increased in 1 [underlined: short-term] study at >6 mg/m^3^; N/C in IgM in 2 studies
FA-Specific IgM or IgA | High or Medium | Human: None | No evidence to evaluate
FA-Specific IgM or IgA | High or Medium | Animal: None | No evidence to evaluate
FA-Specific IgM or IgA | Low | Human: Unclear evidence in 1 long-term study in which a small proportion of subjects appear to have elevated FA-specific IgM (Thrasher et al., 1990): months–years at ≈0.1–1 mg/m^3^ | Evidence could not be interpreted
FA-Specific IgM or IgA | Low | Animal: Isotype unspecified- no change in guinea pigs with acute challenge (Lee et al., 1984) at 2.5 or 4.9 mg/m^3^ after short term exposure to 7.4 or 12.3 mg/m^3^ (note: no measures without formaldehyde) | Evidence could not be interpreted
Antigen-Specific IgM or IgA (does not include FA-specific Ig) | High or Medium | Human: None | No evidence to evaluate
Antigen-Specific IgM or IgA (does not include FA-specific Ig) | High or Medium | Animal: None | No evidence to evaluate
Antigen-Specific IgM or IgA (does not include FA-specific Ig) | Low | Human: N/C in airway pathogen bacteria-specific IgM or IgA in one study in children (Erdei et al., 2003): unknown duration (likely months to years) at <0.1 mg/m^3^ | The minimal data available suggest that formaldehyde does not alter these parameters
Antigen-Specific IgM or IgA (does not include FA-specific Ig) | Low | Animal: N/C in IgM specific to vaccine antigens in rats (Holmstrom et al., 1989a): 22 mos at 15.5 mg/m^3^ (s.c. injection) | The minimal data available suggest that formaldehyde does not alter these parameters
Immune and Inflammation-Related Changes in the Blood
[[See Table A-81 for Cellular and Cytokine Response in Blood]]
Oxidative Stress | High or Medium | Human: Increased marker of lipid peroxidation in adult serum lymphocytes (Bono et al., 2010): likely months to years (assumed) at ≥0.066 mg/m^3^; Increased F2-Isoprostanes (suggested as the best in vivo biomarker of lipid peroxidation) in urine (Romanazzi et al., 2013): 0.21 mg/m^3^ chronic occupational (indirect), although smoking and formaldehyde were not additive, both were independently associated with ROS―Note: serum and urine IsoP measures are correlated (Rodrigo et al., 2007), suggesting that urine levels may reflect similar serum changes | Two studies in adults indicate elevated oxidative stress markers in blood at ≥0.066 mg/m^3^ with [underlined: longterm] exposure. Given the uncertainty with concluding urine levels exhibit the same pattern of association as blood, 1 study contributes as indirect evidence | Moderate ↑
Oxidative Stress | High or Medium | Animal: None | | Moderate ↑
Oxidative Stress | Low | Human: Increased oxidative stress biomarkers (F2-Isoprostanes; malondialdehyde) in urine (Bellisario et al., 2016): ≈0.034 mg/m^3^ work shift occupational (indirect; responses likely reflect short-term exposure) | Several studies in three species suggest increases in markers of oxidative stress with [underlined: acute] or [underlined: short-term]; it is not clear whether and to what extent this persists with long-term exposure | Moderate ↑
Oxidative Stress | Low | Animal: Increased oxidative stress markers in mice (Ye et al., 2013; Matsuoka et al., 2010): acute or short-term as low as 0.12 mg/m^3^; increased markers and protein indicators in rats (Im et al., 2006; Aydin et al., 2014): short term at 6.48–12.3 mg/m^3^, although 1 study with longer exposure observed a decrease in MDA, but decreased SDH in lymphocytes (Katsnelson et al., 2013): 10 wk at 12.8 mg/m^3^; other indicators including decreased GSH (Ye et al., 2013; Katsnelson et al., 2013) and increased NO and SOD (Matsuoka et al., 2010) at ≥1 mg/m^3^ | | Moderate ↑
Circulating Stress Hormones | High or Medium | Human: None | Increased stress hormone at 3 mg/m^3^ formaldehyde in a single rodent study with [underlined: short-term], but not acute, exposure | Slight ↑
Circulating Stress Hormones | High or Medium | Animal: Increased corticosterone in rats with short-term, but not acute, exposure (Sorg et al., 2001a): ≈3 mg/m^3^ | Increased stress hormone at 3 mg/m^3^ formaldehyde in a single rodent study with [underlined: short-term], but not acute, exposure | Slight ↑
Circulating Stress Hormones | Low | Human: None | No evidence to evaluate | Slight ↑
Circulating Stress Hormones | Low | Animal: None | No evidence to evaluate | Slight ↑
Altered Immune Function | High or Medium | Human: None | No evidence to evaluate | Indeterminate
Altered Immune Function | High or Medium | Animal: None | No evidence to evaluate | Indeterminate
Altered Immune Function | Low | Human: Increased autoantibodies in adults (Thrasher et al., 1990): long-term at 0.06–0.95 mg/m^3^ | 1 study in adults suggests that autoantibodies are elevated with low level, [underlined: long-term] exposure; somewhat in contrast, 1 mouse study suggests short-term high level exposure improves host response to bacteria | Indeterminate
Altered Immune Function | Low | Animal: Improved cell-mediated immune response to bacteria challenge, but N/C against tumor challenge or delayed-type hypersensitivity response in mice (Dean et al., 1984): 3 wk at 18.5 mg/m^3^; however, N/C in vitro measures of immune cell function. | | Indeterminate
Changes in Other Immune-related tissues
Cell counts in immune tissues (not including bone marrow) | High or Medium | Human: None | Suppression of CD8+ T cells in immune tissues (e.g., spleen) is indicated in one 8-wk mouse study, with indirect support from a second short-term mouse study, at around 2 mg/m^3^; effects on CD4^+^/CD8^+^ ratio were mixed across 2 subchronic mouse studies | Moderate; (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (in spleen: ↑ at low level; ↓ at high level); Indeterminate for other cell counts
Cell counts in immune tissues (not including bone marrow) | High or Medium | Animal: Decreased CD8+ T cells and increased CD4^+^/CD8^+^ ratio in both thymus (immature immune cells) and spleen (mature immune cells) in male mice (Ma et al., 2020): Eight weeks of exposure at 2 mg/m^3^; No change in splenic CD4^+^/CD8^+^ ratio in female mice (Fujimaki et al., 2004b): 12 wk at up to 2.46 mg/m^3^; Increased splenic regulatory T cells (subset of CD4+) and indirect markers for suppression of effector T cell (CD8+) activity in female mice (Park et al., 2020): short-term exposure at ≥1.38 mg/m^3^ | | Moderate; (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (in spleen: ↑ at low level; ↓ at high level); Indeterminate for other cell counts
Cell counts in immune tissues (not including bone marrow) | Low | Human: None | Multiple [underlined: short-term] mouse studies suggest that overall splenic cell T and B cells are unchanged; however, 2 studies suggest that NK cells may be affected (1 study showed NK cells were stimulated at low formaldehyde levels, and another that high levels are inhibitory/toxic) | Moderate; (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (in spleen: ↑ at low level; ↓ at high level); Indeterminate for other cell counts
Cell counts in immune tissues (not including bone marrow) | Low | Animal: N/C in tissue weight, total cellularity or T or B cell counts in mice (Kim et al., 2013a; Gu et al., 2008; Dean et al., 1984); altered NK cell number and function was noted in mice, with one study showing decreases (Kim et al., 2013a): 2–3 wk at 12.3 mg/m^3^, and another showing increases (Gu et al., 2008): 5 wk at up to 0.12 mg/m^3^, and a third showing N/C in lymphocyte proliferation, functional parameters, IgM production, or NK cytotoxicity (Dean et al., 1984): 3 wk at 18.5 mg/m^3^ | | Moderate; (for ↓ CD8+ T cell response in spleen and thymus); Slight; NK cells (in spleen: ↑ at low level; ↓ at high level); Indeterminate for other cell counts
Splenic and Lymph Cytokines and other Markers | High or Medium | Human: None | No evidence to evaluate | Slight ↑ oxidative stress and cytokine production, especially in response to antigen
Splenic and Lymph Cytokines and other Markers | High or Medium | Animal: None | No evidence to evaluate | Slight ↑ oxidative stress and cytokine production, especially in response to antigen
Splenic and Lymph Cytokines and other Markers | Low | Human: None | 1 [underlined: short-term] mouse study suggests increased oxidative stress at ≥1 mg/m^3^, and another ↓ IL-13 at 0.25–1.23 mg/m^3^, and 3 others suggest that the response (splenic or lymph) to antigen stimulation (and 1 study without stimulation), most notably increased IL-4, is exacerbated at ≥0.25 mg/m^3^ formaldehyde | Slight ↑ oxidative stress and cytokine production, especially in response to antigen
Splenic and Lymph Cytokines and other Markers | Low | Animal: Spleen: ↑ oxidative stress markers in mice (Ye et al., 2013): 7 d at ≥1 mg/m^3^); exaggerated IFNγ response (at 2.46 mg/m^3^) of lymphocytes to LPS and ↑ MCP-1 response to OVA in mice (Fujimaki et al., 2004b): 12 wk at ≥0.49 mg/m^3^; ↓ IL-13 (Kim et al., 2013a): short-term at 0.25–1.23 mg/m^3^; with allergen (HDM), exacerbated ↑ in IL-4, IL-5, IL-13, and IL-17a, but ↓ IFNγ (Kim et al., 2013a): short-term at 0.25 or 1.23 mg/m^3^; Lymph Nodes: ↑ IL-4 and IL-10 (and IL-12, slightly), but N/C in IFNγ in mice with sensitization (De Jong et al., 2009): 4 wk at 3.6 mg/m^3^; thymus: ↑ IL-4 and IL-1B in mice (Jung et al., 2007): shortterm (2 wk) at ≥0.5 mg/m^3^ | | Slight ↑ oxidative stress and cytokine production, especially in response to antigen
Bone Marrow Cell Counts and Function | High or Medium | Human: None | No evidence to evaluate | Indeterminate
Bone Marrow Cell Counts and Function | High or Medium | Animal: ↑ bone marrow hyperplasia in rats (Kerns et al., 1983): 24 mos at 17.6 mg/m^3^ | No evidence to evaluate | Indeterminate
Bone Marrow Cell Counts and Function | Low | Human: None | 1 mouse study suggests BM megakaryocytes may be increased with [underlined: short-term] exposure at ≥0.5 mg/m^3^; Total cell counts are unchanged with short-term exposure at ≤20 mg/m^3^ in 2 mouse studies, while excessive levels appear to cause toxicity | Indeterminate
Bone Marrow Cell Counts and Function | Low | Animal: In mice: N/C in cell counts or functional properties in mice (Dean et al., 1984): 3 wk at 18.5 mg/m^3^ [Note: thymus measures also unchanged]; Bone marrow toxicity, impaired function, and decreased cell counts at excessive levels (Yu et al., 2014b; Yu et al., 2015a): short-term at ≥40 mg/m^3^; increased megakaryocytes (Zhang et al., 2013): short-term at ≥0.5 mg/m^3^ | | Indeterminate
Bone Marrow Cytokines and other Markers | High or Meduium | Human: None | Indirect evidence suggests no changes at ≤2.46 mg/m^3^ | Slight ↑ oxidative stress and inflammation
Bone Marrow Cytokines and other Markers | High or Meduium | Animal: N/C in BM mRNAs or miRNAs in rats (Rager et al., 2014): short term at 2.46 mg/m^3^ | Indirect evidence suggests no changes at ≤2.46 mg/m^3^ | Slight ↑ oxidative stress and inflammation
Bone Marrow Cytokines and other Markers | Low | Human: | 3 mouse studies suggest that oxidative stress is increased with [underlined: short-term] exposure, even at 0.5 mg/m^3^. 1 short-term mouse study suggests the BM is damaged and inflamed, while 1 longer-term rat study suggests there is no damage | Slight ↑ oxidative stress and inflammation
Bone Marrow Cytokines and other Markers | Low | Animal: ↑ indicators of oxidative stress in mice (Zhang et al., 2013; Yu et al., 2014b; Yu et al., 2015a; Ye et al., 2013): short-term at ≥0.5 mg/m^3^; increased markers of cell death (caspase-3) and inflammation (↑ NFkB, TNFα, IL-1β) in mice (Zhang et al., 2013; Yu et al., 2015a): short-term at 3 and 20 mg/m^3^, respectively; N/C in DNA or RNA measures of proliferation and health in rats (Dallas et al., 1987): subchronic at 0.62–18.5 mg/m^3^ | | Slight ↑ oxidative stress and inflammation

Table C-35 Summary of changes in blood cell counts and immune factors as a result of formaldehyde exposure

Endpoint(s) | | | No changes observed; (high or medium confidence experiments are bolded) | | Significant^a^ increases or decreases; (high or medium confidence experiments are bolded) | | Summary conclusion Clarifying notes
Endpoint(s) | | | Duration^b^ (species) | Concentration(s) [notes] (study) | Duration (species) ^b^ | Concentration(s) [notes] (study) | Summary conclusion Clarifying notes
White blood cells (WBCs) | Total WBCs | | Years (humans); Years (humans); Short term (mice); Years (children) | 0.87 mg/m^3^ (Lyapina et al., 2004); 0.25 mg/m^3^ (Aydın et al., 2013); ≥9.23 mg/m3 (Morgan et al., 2017); ≈0.02 mg/m3 [year assumed] 90767 | Years (humans); Short term (rats); Years (humans); Unclear^c^ (humans); Short term (mice) | ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2014); [indirect]; ↓ ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997); ↓ N/A^h^ (≤1 mg/m^3^) [years, not months] (Thrasher et al., 1990); ↓ 0.5–3 mg/m3 (Zhang et al., 2013) | Moderate ↓ ^4^; Possibly concentration- and/or duration-dependent, but this dependence is [underlined: unclear]
White blood cells (WBCs) | Granulocytes | All | Short term (mice) | 18.5 mg/m^3^ [WBC differentials^d^] (Dean et al., 1984) | Years (humans) | ↓ 1.6 mg/m^3^(Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016) | Slight↓; most likely neutrophils at higher concentrations with [underlined: short-term] or [underlined: longer] exposure
White blood cells (WBCs) | Granulocytes | Neutrophils | Years (humans); Short term (mice); Years (children); Years (humans); Short term (mice) | 0.25 mg/m^3^ (Aydın et al., 2013); ≥9.23 mg/m^3^ (Morgan et al., 2017); ≈0.02 mg/m^3^ [year assumed] (Erdei et al., 2003); ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997); 0.5–3 mg/m^3^ (Zhang et al., 2013) | Years (humans); Short term (rats) | ↓ 0.87 mg/m^3^ [note: function, not counts, in workers with URT dysfunction] (Lyapina et al., 2004); ↓ 13 mg/m3 (Katsnelson et al., 2013) | Slight↓; most likely neutrophils at higher concentrations with [underlined: short-term] or [underlined: longer] exposure
White blood cells (WBCs) | Granulocytes | Eosinophils | Short term (mice); Years (children); Years (humans) | ≥9.23 mg/m^3^ (Morgan et al., 2017); ≈0.02 mg/m^3^ [year assumed] (Erdei et al., 2003); ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997) | | | Slight↓; most likely neutrophils at higher concentrations with [underlined: short-term] or [underlined: longer] exposure
White blood cells (WBCs) | Granulocytes | Basophils | Years (humans) | ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997) | | | Slight↓; most likely neutrophils at higher concentrations with [underlined: short-term] or [underlined: longer] exposure
White blood cells (WBCs) | Lymphocytes | All | Months (humans); Short term (mice); Years (children); Years (humans); Weeks (humans); Unclear^c^ (humans); Short term (mice) | 0.2–0.8 mg/m^3^ (Jia et al., 2014); ≥9.23 mg/m^3^ (Morgan et al., 2017); ≈0.02 mg/m^3^ [year assumed] (Erdei et al., 2003); ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997); 0.51 mg/m^3^ (Ying et al., 1999); N/A^h^ (≤1 mg/m^3^) [years vs. months] (Thrasher et al., 1990); 18.5 mg/m^3^ [WBC differentials^e^] (Dean et al., 1984) | Years (humans); Years (humans); Short term (mice); Short term (rats) | ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); ↑ 0.25 mg/m^3^ (Aydın et al., 2013); ↓ 0.5–3 mg/m3 (Zhang et al., 2013); ↑ 13 mg/m^3^ (Katsnelson et al., 2013) | Indeterminate; multiple changes noted, but pattern is indiscernible
White blood cells (WBCs) | Lymphocytes | B Cells | Years (humans); Years (humans); Years (humans) | 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); 0.25 mg/m3 (Aydın et al., 2013); 0.09–0.68 mg/m^3^ (Thrasher et al., 1987) | Years (humans); Months (humans); Months (humans); Years (humans); Unclear^c^ (humans); Weeks (humans) | ↓ 0.36 [up to 0.69 peaks] mg/m^3^ (Costa et al., 2013); ↑ 0.99 [up to 1.69 peaks] mg/m^3^ (Ye et al., 2005); ↑ 0.2 and 0.8 mg/m^3^ (Jia et al., 2014); ↓ 0.47 [up to 3.94 peaks] mg/m^3^ (Costa et al., 2019); ↑ N/A^h^ (≤1 mg/m^3^) [years, not months] (Thrasher et al., 1990); ↑ 0.51 mg/m^3^ (Ying et al., 1999) | Moderate; For altered number of B cells (direction of change may differ by exposure levels or duration)
White blood cells (WBCs) | Lymphocytes | T Cells (Total) | Months (humans); Unclear^c^ (humans) | 0.2–0.8 mg/m^3^ (Jia et al., 2014); N/A^h^ (≤1 mg/m^3^) [years vs. months] (Thrasher et al., 1990) | Years (humans); Months (humans; Years (humans); Years (humans); Years (humans); Years (humans); Weeks (humans); Short term (rats) | ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); ↓ 0.99 [up to 1.69 peaks] mg/m^3^ (Ye et al., 2005); ↑ 0.36 [up to 0.69 peaks] mg/m^3^ (Costa et al., 2013); ↑ 0.25 mg/m^3^ (Aydın et al., 2013); ↓ 0.09–0.68 mg/m^3^ (Thrasher et al., 1987); ↓ 0.9 mg/m^3^ [indirect: apoptosis] (Jakab et al., 2010); ↓ 0.51 mg/m3 (Ying et al., 1999); ↑ 7.4 mg/m^3^ (Sandikci et al., 2007a, b) | Slight; mixed results suggests concentration-dependence, with ↓ at higher levels (possibly ↑ at low levels) with [underlined: months–years] exposure
White blood cells (WBCs) | Lymphocytes | T Cells (CD4^+^) | Years (humans); Months (humans); Years (humans); Years (humans); Months (humans) | 1.6 mg/m^3^ [↓ T_reg_] (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); 0.99 [up to 1.69 peaks] mg/m^3^ (Ye et al., 2005); 0.47 [up to 3.94 peaks] mg/m^3^ (Costa et al., 2019); 0.25 mg/m^3^ (Aydın et al., 2013); 0.2–0.8 mg/m^3^ (Jia et al., 2014) | Years (humans); Weeks (humans) | ↑ 0.36 [up to 0.69 peaks] mg/m^3^ (Costa et al., 2013); ↓ 0.51 mg/m3 (Ying et al., 1999) | Indeterminate; data suggest N/C, but variable, considering also studies of spleen above, suggests effects may exist at CD4 subset level
White blood cells (WBCs) | Lymphocytes | T Cells (CD8^+^) | Years (humans); Years (humans); Months (humans) | 0.25 mg/m^3^ (Aydın et al., 2013); 0.36 [up to 0.69 peaks] mg/m^3^ (Costa et al., 2013); 0.2–0.8 mg/m3 (Jia et al., 2014); [N/C CD4/CD8 ratio in 3 studies and (Thrasher et al., 1990) | Years (humans); Months (humans); Years (humans); >Weeks (humans) | ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013); ↓ 0.99 [up to 1.69 peaks] mg/m^3^ (Ye et al., 2005); ↑ 0.47 [up to 3.94 peaks] mg/m^3^ (Costa et al., 2019); ↓ 0.51 mg/m^3^ (Ying et al., 1999) [↑ CD4/CD8 ratio in all but one of these studies] | Moderate ↓ CD8 and ↑ CD4/CD8 ratio likely related to concentration
White blood cells (WBCs) | Lymphocytes | NK Cells | | | Years (humans); Years (humans); Years (humans); Months (humans) | ↓ 0.36 [up to 0.69 peaks] mg/m^3^ (Costa et al., 2013); ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); ↑ 0.25 mg/m^3^ (Aydın et al., 2013); ↑ 0.2, but not at 0.8 mg/m^3^ (Jia et al., 2014) | Slight; mixed results suggest role of concentration similar to total T cell findings
White blood cells (WBCs) | Monocytes | | Years (humans); Years (humans); Short term (mice) | 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); 0.25 mg/m3 (Aydın et al., 2013); ≥9.23 mg/m^3^ (Morgan et al., 2017) | Years (children); Short term (mice); Short term (mice) | ↑ ≈0.02 mg/m^3^ [year assumed] (Erdei et al., 2003); ↓ 0.5, but not 3, mg/m^3^ (Zhang et al., 2013); ↓ 18.5 mg/m^3^ (Dean et al., 1984) | Indeterminate; data suggest N/C, at least in human adults
Red Blood Cells | | | Years (humans); Short term (mice); Years (children); Years (humans) | 0.25 mg/m^3^ (Aydın et al., 2013); ≥9.23 mg/m^3^ (Morgan et al., 2017); ≈0.02 mg/m^3^ [year assumed] (Erdei et al., 2003); ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997) | Years (humans); Years (humans); Short term (mice) | ↓ 0.87 mg/m^3^ [note: duration] (Lyapina et al., 2004); ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013); ↓ 0.5–3 mg/m^3^ (Zhang et al., 2013) | Moderate ↓^6^; suggests combined role of concentration and duration
Platelets | | | Years (humans); Short term (mice); Years (children); Years (humans) | 0.87 mg/m^3^ (Lyapina et al., 2004); ≥9.23 mg/m^3^ (Morgan et al., 2017); ≈0.02 mg/m^3^ [year assumed] (Erdei et al., 2003); ≤0.29 mg/m^3^ [mean levels] (Kuo et al., 1997) | Years (humans); Short term (mice) | ↓ 1.6 mg/m^3^ (Zhang et al., 2010; Hosgood et al., 2013; Bassig et al., 2016); ↑ 0.5–3 mg/m^3^ (Zhang et al., 2013) | Slight ↓ ^7^; possible concentration dependence similar to above
Secreted factors and immune | Primarily Th1-related | TNF-α | Years (humans); Months (humans) | 1.8 [up to 6.9 peaks] mg/m^3^ (Seow et al., 2015); 0.2-0.8 mg/m^3^ (Jia et al., 2014) | Years (humans) | ↑ 0.25 mg/m^3^ (Aydın et al., 2013) | Slight ↑ TNF-α and C3
Secreted factors and immune | Primarily Th1-related | Complement | Years (humans) | (C3, C4) 0.25 mg/m^3^ (Aydın et al., 2013) | Short term (rats) | ↑ (C3) 6.15 mg/m^3^ (Sapmaz et al., 2015) | Slight ↑ TNF-α and C3
Secreted factors and immune | Primarily Th1-related | IFN-γ | | | Months (humans); Short term (rats) | ↓ 0.8, but not 0.2, mg/m^3^ (Jia et al., 2014); ↓ 6.2–12.3 mg/m^3^ (Im et al., 2006) | Moderate ↓ IFN-γ
Secreted factors and immune | Primarily Th2-related | IL-4 | | | Months (humans); Short term (rats) | ↑ 0.8, but not 0.2, mg/m^3^ (Jia et al., 2014); ↑ 6.2–12.3 mg/m^3^ (Im et al., 2006) | Moderate ↑ IL-4
Secreted factors and immune | Primarily Th2-related | IL-10 | | | Years (humans); Months (humans) | ↓ 1.8 mg/m^3^ [less strict 20% FDR] (Seow et al., 2015); ↑ 0.2–0.8 mg/m^3^ (Jia et al., 2014) | Slight IL-10; [underlined: Suggestive] of concentration role similar to total T and NK cell findings
Secreted factors and immune | Primarily Th2-related | IL-6 | Acute (mice) | 0.12 mg/m^3^ (Matsuoka et al., 2010) | | | Inadequate IL-6
Secreted factors and immune | Chemo-attractants | CXCL11 (IFNγ-related) | | | Years (humans) | ↓ 1.8 mg/m^3^ [stringent 10% FDR] (Seow et al., 2015) | Slight ↓; chemoattractants (attracting neutrophils-IL-8, and lymphocytes-Cxcl11, Ccl17)
Secreted factors and immune | Chemo-attractants | CCL17 (Th2*related) | | | Years (humans) | ↓ 1.8 mg/m^3^ [stringent 10% FDR] (Seow et al., 2015) | Slight ↓; chemoattractants (attracting neutrophils-IL-8, and lymphocytes-Cxcl11, Ccl17)
Secreted factors and immune | Chemo-attractants | IL-8 (neutrophils) | | | Months (humans) | ↓ 0.2–0.8 mg/m^3^ (Jia et al., 2014) | Slight ↓; chemoattractants (attracting neutrophils-IL-8, and lymphocytes-Cxcl11, Ccl17)
Secreted factors and immune | Other | Ta1 | | | Unclear ^3^ | ↑ N/A^h^ (≤1 mg/m^3^) [years, not months, change in (humans) antigen reactivity markers] (Thrasher et al., 1990) | Indeterminate; (data suggest N/C in B cell activation markers)
Secreted factors and immune | Other | IL-2R | | | Unclear ^3^ | ↑ N/A^h^ (≤1 mg/m^3^) [years, not months, change in (humans) antigen reactivity markers] (Thrasher et al., 1990) | Indeterminate; (data suggest N/C in B cell activation markers)
Secreted factors and immune | Other | CD27 and CD30 | Years (humans) | 1.6 mg/m^3^ (Bassig et al., 2016) | | | Indeterminate; (data suggest N/C in B cell activation markers)

Der f: Dermatophagoides farina (house dust mite); OVA: ovalbumin (major protein of chicken egg whites); both are immunogenic materials used to stimulate an allergy-like response.

Gray box = no data meeting the inclusion criteria were available.

Note: one study observing increased substance P and related changes in the serum (Fujimaki et al., 2004b) is primarily discussed in the context of changes in the URT and LRT.

a Primarily, this reflects reporting of a statistically significant change; in rare instances where a p value was not given, changes are indicated if the authors discussed the change as a significant effect.

b Human study exposure durations are indicated as “years,” “months,” “weeks,” or “acute” and defined based on the anticipated exposure duration for the majority of the exposed population(s); these durations are interpreted to approximate animal study exposure durations of chronic (>1 year), subchronic (several months), short term (<30 days), and acute (1 day or less).

c The comparison presented by Thrasher et al. (1990) reflects differences in exposure duration (years compared to weeks or months), but there appeared to be minimal difference in concentration.

d This finding (decreased total WBCs) is supported by 3 studies in humans evaluated by the NRC (2014) (Tong et al., 2007; Tang and Zhang, 2003; Cheng et al., 2004), but not evaluated in this analysis; additionally, this finding is supported by a study in mice (Yu et al., 2014b) and a study in rats (Brondeau et al., 1990), which are not included as they only tested formaldehyde levels ≥20 mg/m^3^.

e Authors indicated no changes in “WBC differentials” other than decreased monocytes, but further details NR (Dean et al., 1984). This test was assumed to include basic granulocyte and lymphocyte counts.

f This finding (decreased erythrocytes) is supported by 1 study in humans evaluated by the NRC (2014) (Yang, 2007), but not evaluated in this analysis.

g This finding (decreased platelets) is supported by 2 studies in humans evaluated by the (2014) (Yang, 2007; Tong et al., 2007), but not evaluated in this analysis, and a mouse study testing excessive formaldehyde levels (Yu et al., 2014b).

h The exposure level is, in general, considered not applicable (N/A), as the comparison presented by Thrasher et al. (1990) reflected differences in exposure duration (i.e., years of exposure [Yr], as compared to weeks or months [Mo] of exposure), but there appeared to be minimal differences in concentration from the controls.

### C.7.4 Integrated Mechanistic Evidence Synthesis by Tissue Compartment

The most likely initial effects of formaldehyde exposure include evidence of direct interactions of formaldehyde with biological macromolecules (e.g., DNA; receptors; redox proteins) in the upper respiratory tract (URT). These direct interactions would typically not be expected to occur in other tissue compartments given the lack of substantial distribution of inhaled formaldehyde to distal sites (see Appendix C.1). While stress hormone increases likely involve prior modification of the hypothalamic-pituitary-adrenal (HPA) axis, slight evidence of this change is indicated as a plausible initial effect of exposure due to a general lack of knowledge of the specific type of stressor(s) (e.g., direct responses due to subtle changes in fear or anxiety; indirect effects via sustained inflammation) and the nature of the interactions with the HPA axis that might result from formaldehyde inhalation. The slight evidence of indirect evidence for sensory nerve stimulation in the LRT is not indicated as a plausible initial effect of exposure because inhaled formaldehyde is unlikely to reach the LRT in appreciable amounts and it is expected that LRT sensory nerve activation would be reliant on a secondary response to TRP channel-activating stimuli such as increased LRT oxidative stress or inflammatory mediators; although, certain exposure scenarios (e.g., after exposure to high levels of formaldehyde or mouth breathing during exercise, perhaps only in susceptible individuals) might, in rare scenarios, result in distribution of minimal amounts of formaldehyde to upper regions of the LRT (see Appendix C.1) that may be sufficient to induce such receptor-mediated events. Although it is difficult to disentangle the multiple mechanistic events manifested soon after formaldehyde inhalation, it appears that formaldehyde can initiate overlapping events in the URT, including effects at the level of the respiratory epithelial cells and overlying mucociliary layer, as well as at trigeminal nerve endings. While uncertainties remain^19^, the effects in the lower respiratory tract (LRT), blood, and other organs are likely secondary to the changes observed in the URT. Figures C-23 and C-24 illustrate the potential relationships between the mechanistic events reported from formaldehyde exposure, based on the more reliable evidence (see Figure C-23) or including evidence that should be interpreted with greater caution (see Figure C-24). These figures are based on evidence summarized in the tables in the prior sections (Appendix C.7.1 to C.7.3), and they are discussed according to tissue compartment below.

Figures C-23 and C-24 (on the following pages) present network summaries of mechanistic data related to potential noncancer respiratory health effects of formaldehyde. These figures present an integrated picture of the mechanistic events identified from studies of formaldehyde exposure. The figures are organized by tissue type or region (i.e., upper respiratory tract, “URT”; lower respiratory tract, “LRT”; “blood”; and other tissues related to immunological responses, “other”), the data for which are summarized in the following subsections. Figure C-23 presents events interpreted with greater confidence (i.e., robust, or moderate evidence), while Figure C-24 includes events based on slight evidence. In both figures, the mechanistic events and the relationships between events are characterized. Lines with arrows on both ends indicate events for which the association appears to be bidirectional. The figures also identify events that are “plausibly an initial effect of exposure,” and each event is related to one or more “key features of a potential hazard” (see explanations in Section 2.5.1 of the Toxicological Review). Note: Some events and relationships are not shown for clarity, but nearly all mechanistic events discussed in Appendix C.7.1 to C.7.3 for which at least slight evidentiary support was concluded are presented. Note that “decreased pulmonary function” encompasses a range of possible contributing effects including, but not limited to, increased bronchoconstriction, flow limitation, and decreased bronchodilation.

Figure C-23 Mechanistic events for respiratory effects of formaldehyde based on robust or moderate evidence

Figure C-24 Mechanistic events for respiratory effects of formaldehyde based on robust, moderate, or slight evidence

#### Consideration of mechanistic changes across tissue compartments

Several interesting relationships across tissue compartments are suggested:

- Evidence of increased oxidative stress, in particular, appears to be conserved across each of the evaluated tissue compartments. As soluble inflammatory signals can be transmitted across tissue boundaries with relative ease, it is plausible that these indications of an increased body burden of free radicals may be an indirect consequence of inflammatory changes that could be relatively restricted to the airways.
- Observations of increased eosinophils, and to a somewhat lesser extent, neutrophils, in both the URT and LRT, suggest that the inflammation of the airways caused by formaldehyde exposure is not restricted to the URT sites directly contacted by the majority of inhaled formaldehyde.
- Although some more subtle changes appear to occur in the LRT (e.g., inflammation; altered airway permeability), the data suggest that overt damage to the airway epithelium by formaldehyde exposure is limited primarily to the URT.
- Key features of several potential health hazards appear to involve mechanistic changes occurring within multiple tissue compartments, including decreased pulmonary function and allergic sensitization.
- Although many uncertainties remain, the instances of opposing immune-related responses in the airways compared to those in the blood suggest immunological communication and possible recruitment of cells from one compartment to another. One exception to this pattern was the consistent observation of increased IL-4 in both the LRT and blood. IL-4 is associated with driving CD4+ T cells towards a Th2 response (Kopf et al., 1993). The evidence specific to changes in CD4+ T cell populations in either compartment were inadequate, limiting interpretations of the significance of this finding.
- While many immune-cell-related changes were observed, some only occurred in specific exposure contexts. For example, neutrophil and monocyte increases in the LRT were observed only with allergen sensitization, while eosinophil increases were not observed in studies of exposure less than several weeks; changes in NK cells and other lymphocytes subsets appeared to vary depending on concentration, and some antibody responses depended on the antigen (e.g., allergen) type and administration methods. In addition, immune system studies after developmental exposure represent a significant data gap.
- In general, the evidence becomes less convincing with increasing removal from the point-of-first-contact for inhaled formaldehyde, with the highest confidence for effects in the URT, slightly less confidence for effects in the LRT and blood, and a general inability to draw conclusions regarding the potential for effects in lymphoid organs.

#### Plausibility of potential associations between mechanistic changes and respiratory system health effects

Figure C-25 illustrates one or more potential sequences of events from formaldehyde inhalation to apical outcomes (i.e., key hazard features) described in each of the respiratory system health effects sections in the Toxicological Review. Each of these sequences was developed based on the most reliable mechanistic evidence (i.e., robust or moderate evidence was preferred) that can plausibly link an initial effect of inhaled formaldehyde to each of these key hazard features, and which have been demonstrated in formaldehyde-specific studies. Thus, these sequences do not represent all possible scenarios for which data exist (see Figures C-23 and C-24 for more comprehensive illustrations), and data not considered in this analysis (e.g., studies of chemicals closely related to formaldehyde) could identify additional initial alterations and mechanistic events, as well as more interim changes or relationships between many of the depicted mechanistic events. As such, this figure may not illustrate the most biologically pertinent sequence of events, but it does illustrate biologically plausible pathways of effects based on data specific to formaldehyde exposure. Thus, this is a pragmatic attempt to link early mechanistic events with apical endpoints, similar to the AOP conceptual framework (Villeneuve et al., 2014; Ankley et al., 2010). For each sequence, an interpretation regarding the likelihood of the presented sequence of events being a mechanism by which formaldehyde inhalation could cause respiratory system health effects is provided in the section below. As these interpretations are based on the robustness of the available evidence, they are primarily based on confidence in the individual studies and the consistency and coherence of observations across species and experimental paradigms. Other considerations outlined by Sir Bradford Hill (1965), including the magnitude and dose-dependency of the individual study findings, are discussed where the data are available, but these considerations generally had less of an impact on interpretations. This section references evidence conclusions from previous sections, as well as studies supporting biological understanding, but individual formaldehyde-specific studies are generally not referenced.

Figure C-25 Possible sequences of mechanistic events identified based on the most reliable evidence available

This figure presents plausible mechanistic pathways illustrating the most reliable formaldehyde exposure-specific data (i.e., robust or moderate evidence was preferred) based on currently available information. The figure is organized by respiratory system health effect represented by key features of each hazard evaluated in the Toxicological Review. The pathways interpreted to most plausibly link possible initial effects of formaldehyde exposure to these apical events is presented, based on both the confidence in the relationships between events and confidence in the evidence for each of the linked mechanistic events. These pathways^20^ are organized in a linear fashion from initial event(s) to key hazard feature(s), and each pathway is numbered, corresponding to the synthesis that follows. The mechanistic events are grouped into “initial events” and “secondary events” for endpoints that would be expected to occur earlier and later, respectively, along a sequential mechanistic progression. Generally, for the “initial” events, a preceding or precursor event other than a direct interaction with formaldehyde is unknown or has not been studied following formaldehyde exposure, or they have been described in previous pathways (e.g., see #6). “Effector-level changes” are those events that are most likely to be directly associated with the apical endpoint(s) of interest. The symbols, descriptors, and arrows are the same as those depicted in Figures C-23 and C-24.

##### 1) Respiratory tract pathology (squamous metaplasia) through epithelial cell damage

[underlined: Interpretation]: This is likely to be a major mechanism by which formaldehyde inhalation could cause squamous metaplasia.

Consistent with its known chemistry and reactivity, formaldehyde has been shown to react with DNA and other biological macromolecules at the point of first contact in the URT, where it also affects tissue redox capacity, presumably either through direct interactions with cellular macromolecules (e.g., lipids) or indirectly by impacting local tissue detoxification processes. These initial reactions have been shown to occur following acute and short-term exposure at concentrations <0.5 mg/m^3^, and generally, the magnitude of these effects is expected to be driven largely by formaldehyde concentration and distribution. Distribution of formaldehyde-induced nasal lesions progresses to more posterior locations with chronic exposure; presumably, this represents changes in formaldehyde deposition, although this has not been tested. Additionally, studies have not been performed to address whether long-term exposure may overcome the body’s capacity to regulate or restrict the magnitude of these changes. Elevated oxidative stress could directly lead to cytotoxic or subcytotoxic epithelial cell damage and/or dysfunction through the modification of cellular proteins and DNA. Because similar endogenous defense mechanisms (e.g., glutathione) are responsible for the detoxification of some free radicals and formaldehyde, persistent oxidative stress may make these cells more prone to damage directly resulting from formaldehyde and other inhaled agents. DNA-protein crosslinks (DPXs), which have been observed at formaldehyde concentrations ≥0.3 mg/m^3^ (rats) or ≥0.9 mg/m^3^ (rhesus monkeys) and durations ≥3 hours (see Appendix C.3), can lead to cellular damage if they are not repaired. Formaldehyde can modify the structure and function of the mucociliary apparatus, potentially as a result of covalent modification of soluble factors in the mucus (Morgan et al., 1984) or ciliary proteins (Hastie et al., 1990). Studies of the mucociliary apparatus following acute exposure provide evidence for a concentration threshold for functional effects, again highlighting the importance of formaldehyde concentration and distribution. In rats, DPXs and regions of mucociliary dysfunction have both been demonstrated to correlate with locations of subsequent respiratory tract pathology and cell proliferation in the anterior portions of the nasal mucosa following formaldehyde exposure. The resultant, potentially adaptive, effects on cellular proliferation (i.e., hyperplasia) are typically dose- and duration-dependent and localized to regions of mucociliary dysfunction and epithelial damage. Cellular proliferation may be initiated, at least in part, in response to formaldehyde exposures not associated with histopathological evidence of epithelial cell damage, since some studies report effects on proliferation at ≈1 mg/m^3^. Direct and overt epithelial cell damage or death associated with squamous metaplasia is not typically observed until formaldehyde concentrations are above 2 mg/m^3^. Squamous metaplasia is also localized initially to these high-flux, anterior regions, but these lesions increase in severity and advance to more posterior locations with longer exposure. Thus, although some early mechanistic events in this pathway are expected to be highly dependent on formaldehyde concentration, the data supports a role for both exposure duration and concentration in the development of long-term lesions such as squamous metaplasia.

All of the events in this mechanism are based on robust or moderate evidence, with robust or moderate evidence for interactions between events, indicating that this mechanism is likely a major mechanism by which formaldehyde inhalation can cause squamous metaplasia. However, because modification of epithelial cell health and function in the URT can occur via multiple direct and indirect mechanisms following formaldehyde inhalation, which are expected to vary due to differences in both exposure duration and intensity, there are likely to be other important mechanisms by which formaldehyde exposure could cause respiratory tract pathology.

##### 2) Sensory irritation through trigeminal nerve stimulation

[underlined: Interpretation]: This is likely to be the dominant mechanism by which formaldehyde inhalation could cause sensory irritation.

With distribution throughout the nasal mucosa, trigeminal nerve endings are well positioned for direct interactions with inhaled formaldehyde. Trigeminal nerve activation at unmyelinated C fibers occurs following acute formaldehyde exposure and the resultant physiological sensation of burning is known to be caused by afferent signaling to the CNS (Mackenzie et al., 1975). This afferent nerve activity has been demonstrated following formaldehyde inhalation. Based primarily on indirect evidence (e.g., ex vivo models), activation of the trigeminal nerve is probably at least partly dependent on direct activation of TRPA1 channels by formaldehyde (e.g., via binding). Further support for an “irritant receptor” response to formaldehyde exposure is provided by evidence of competitive inhibition of irritation caused by chlorine and acetaldehyde (Chang and Barrow, 1984; Babiuk et al., 1985). However, other direct actions of formaldehyde at trigeminal nerve endings (e.g., binding to other receptors; modification of ion balance; protein modification) are possible and some other potential pathway scenarios are suggested. In addition, oxidative stress, such as that elicited in the URT by formaldehyde exposure, is known to activate TRP channels (Bessac and Jordt, 2008), providing another plausible indirect mechanism. Based on the proposed sequence of events, sensory irritation would be expected to be highly variable across individuals due to differences in TRPA1 channel sensitivity or access of formaldehyde to TRPA1 channels (e.g., due to differences in airway structure, mucus production, or TRPA1 channel density). Studies of related chemicals suggest that human sensitivity may also be dependent on demographic factors such as age, sex (women appear to be more sensitive), and allergy status (Shusterman, 2007; Hummel and Livermore, 2002).

The threshold for activation of exposed rodent nerve endings has been reported at 0.31 mg/m^3^ formaldehyde. The levels necessary for in vivo activation following acute exposure may be somewhat higher. Although trigeminal nerve activation may worsen with constant, repeated exposure to low levels of formaldehyde, as has been demonstrated for other chemicals (Brand and Jacquot, 2002), constant exposure or high concentrations could conversely desensitize this response by excessively stimulating the (presumed) irritant receptors. The potential for sensory irritation to attenuate over time due to processes such as desensitization (e.g., via internalization of TRPA1 receptors) is unclear, particularly with long-term exposure. Indirect evidence suggesting either the presence of extremely sensitive individuals in the population or a role for the duration of exposure in eliciting this effect is provided from residential studies identifying symptoms associated with sensory irritation at levels as low as 0.1 mg/m^3^ (Zhai et al., 2013; Liu et al., 1991;Hanrahan et al., 1984). Structural changes to the URT tissue (e.g., formaldehyde-induced modification of the epithelial cell layer altering accessibility of sensory nerve endings) and to the URT response of local immune cells (i.e., inflammatory cells may release mediators which can stimulate proliferation and/or sensitization of sensory nerve fibers (Carr and Undem, 2001) would be expected to be strong modifiers of this effect, introducing an exposure duration component to the concentration-dependence of receptor binding that is assumed for activation of TRPA1.

A strong biological understanding exists to identify the physiological sensation of sensory irritation as being related to stimulated sensory fibers of the trigeminal nerve. While the specific concentration and duration dependency of activation remain incomplete, based on the robust and moderate formaldehyde-specific evidence available to support activation of trigeminal nerve fibers and stimulation of TRPA1 receptors, respectively, along with a general lack of alternative explanations for chemical-induced sensory irritation, this mechanism is likely the dominant mechanism by which formaldehyde exposure can cause sensory irritation.

##### 3) Decreased pulmonary function through URT epithelial damage

[underlined: Interpretation]: This is a possible mechanism by which formaldehyde inhalation could contribute to decreases in pulmonary function, but this is not a major pathway explaining this potential effect, and other changes are expected to be the primary drivers of any substantial functional changes.

Airway epithelial cells not only serve as a physical barrier to inhaled pathogens and antigens, they also participate in the regulation of airway inflammatory responses (Holgate et al., 1999). The demonstrated modification of the respiratory epithelium in the upper airways by formaldehyde exposure may affect pulmonary function through both physical, and humoral mechanisms, although definitive studies for the latter have not been conducted and such factors are generally tightly controlled and locally acting (e.g., Mayer and Dalpke (2007)). Modification to the URT epithelium by formaldehyde, particularly the observed effects on mucociliary function, is also likely to modify URT barrier and clearance processes, which could increase the impact of other inhaled antigens on pulmonary function; however, this possibility has not been well-studied. Physically, swelling of the mucus membrane has been observed in exposed humans at <1 mg/m^3^ formaldehyde, and this is expected to be highly influenced by the underlying respiratory status of the exposed individuals (e.g., allergy status; previous and/or current respiratory infections; etc.). This swelling can plausibly be linked to narrowing of the airways and impaired pulmonary function, although this linkage has not been explicitly demonstrated by corresponding effects in the LRT following formaldehyde exposure and it is unclear to what extent URT swelling would need to progress before effects on lung function were experienced. Morphological changes in the mucous membrane can be related to changes in mucus secretion and, possibly, epithelial cell proliferation (Reader et al., 2003), both of which are observed following formaldehyde exposure. Dysfunction of airway epithelial cells can also modify their release of humoral factors, which help to regulate airway smooth muscle contraction and immune cell responses. For example, epithelial cells can release neutral endopeptidase, which is the major metabolizing enzyme for tachykinins such as substance P and neurokinin A (Barnes, 1992), and they are known to produce situation-specific signals that can either promote or inhibit the activity of local immune cells, including dendritic cells, which contribute to airway remodeling (Lambrecht and Hammad, 2012). In these ways, modification of the function of URT epithelial cells by formaldehyde exposure might result, in an indirect manner, in changes in humoral factors that could reach the lower airways and lungs in minimal amounts. However, direct formaldehyde-specific examinations of such potential associations, including the requisite exposure parameters (e.g., levels), were not identified.

This sequence of events can plausibly link structural damage and dysfunction of the epithelium in the URT to potential decrements in pulmonary function. However, a large amount of missing information, particularly regarding LRT changes, is assumed, and evidence linking these formaldehyde-induced mechanistic events in the URT to changes in pulmonary function has not been reliably demonstrated. While these events might contribute to some minimal level of decrease in pulmonary function, the data are insufficient to identify this sequence of events as a major mechanism.

##### 4) Airway hyperresponsiveness and/or decreased pulmonary function through LRT inflammatory changes resulting from sensory nerve activation

[underlined: Interpretation]: This is likely to be an incomplete mechanism by which formaldehyde inhalation could cause airway hyperresponsiveness and decreased pulmonary function, although whether certain events occur at low exposure levels is unclear.

Activation of airway sensory nerve endings is known to cause the release of neuropeptides, including substance P. Short-term formaldehyde exposure appears to cause increases in substance P, and perhaps other neuropeptides, in the lower airways. In addition, several lines of evidence identify potential substance P-related changes in the LRT that are at least partially dependent on TRP channel activation. As discussed previously, while certain, very rare human exposure scenarios might result in weak activation of the vagus nerve in proximal regions of the LRT (e.g., the trachea) due to direct interactions with formaldehyde, it is expected that the predominant explanation (and that most relevant to interpretations) for activation remains unidentified and involves indirect pathway(s). One possible explanation involves indirect activation of LRT sensory nerve endings in association with the formaldehyde exposure-induced increases in LRT oxidative stress and/or inflammation, as certain electrophilic oxidative byproducts and inflammatory factors can stimulate TRPA1 channels (Taylor-Clark et al., 2008; Andersson et al., 2008). Alternatively, substance P could also be directly released from certain subsets of activated immune cells, including eosinophils (Joos et al., 2000), which are increased in the LRT, although this hypothesis has not been examined and may be somewhat less plausible, given the apparent discrepancy in the exposure duration required for substance P increases versus LRT eosinophil increases in the available studies. Regardless, any indirect pathway(s) would require prior modification of the LRT microenvironment after formaldehyde exposure through a separate, undefined mechanism.

Locally, substance P can cause vasodilation and leakage or constriction of airway smooth muscle, the latter of which appears to be enhanced in asthmatics (who also exhibit elevated substance P-immunoreactivity in airway nerves; (Ollerenshaw et al., 1991), all of which can contribute to airway narrowing or obstruction (Joos et al., 1994; Joos et al., 1995). It should be noted that airway obstruction typically requires much higher doses of agonist than does leakage (e.g., (Yiamouyiannis et al., 1995)). Formaldehyde-induced increases in substance P contribute to microvascular leakage in the LRT (i.e., trachea and main bronchi) following acute formaldehyde exposure, which has been observed at >1 mg/m^3^. Specifically, although the effects of prolonged exposure were not examined, at higher formaldehyde levels (i.e., >10 mg/m^3^) and with acute exposure, microvascular leakage was blocked by inhibition of the neurokinin 1 (NK_1_) receptor, and perhaps also by inhibiting mast cell activation, but not by inhibition of histamine, cyclooxygenases, or bradykinin. Substance P is the preferred substrate for NK_1_ receptors. Although activation of NK_1_ receptors can contribute to structural changes in human airways, these receptors are more commonly associated with increases in airway inflammation (Schuiling et al., 1999). As introduced above, NK_1_ receptors are also implicated in establishing the successful recruitment and adhesion of eosinophils and neutrophils to inflamed airways (Baluk et al., 1995), at which point these cells can release bronchoconstrictors. Thus, the increase in LRT eosinophils observed following formaldehyde exposure (and the slight evidence for increased neutrophils with allergen sensitization) could be related to elevated substance P. In addition, substance P itself can increase the responsiveness of the airways to bronchoconstrictors (Cheung C et al., 1994). Thus, either directly, or indirectly, the release of neuropeptides, presumably from stimulated sensory nerve endings, could result in airway hyperresponsivness. Perhaps relatedly, possible consequences of increased microvascular leakage and inflammation include airway edema and related structural changes, which have been reported following short-term formaldehyde exposures ranging from >0.3 to >3 mg/m^3^ across studies, although these events have not been experimentally linked to sensory nerve stimulation or substance P signaling. Taken together, it is plausible that substance P-mediated inflammatory alterations to the lower airways, were they of sufficient severity, could also lead to decreases in pulmonary function.

Several notable uncertainties exist for this plausible mechanistic pathway. As discussed above, an understanding of the sequence of events preceding the observed changes in the LRT remains largely incomplete. In addition, and perhaps most importantly, while most of the evidence is moderate, the data are based almost exclusively on acute or short-term experiments. Similarly, while evidence for some events at low formaldehyde levels (e.g., <1 mg/m^3^) exists, some of the more convincing associations, including the requirement of NK_1_ receptor activation for microvascular leakage, have only been tested at very high formaldehyde concentrations (e.g., >10 mg/m^3^). Taken together, these limitations raise uncertainties for the relevance of this specific pathway to chronic, low-level exposure scenarios. Further, several important events related to this pathway have not been well studied. For example, the available studies have not examined the potential for sensory nerve activation to modify smooth muscle tone (e.g., regulation of contractile responses through the electrical activity; release of factors with direct action on smooth muscle cells, such as acetylcholine), and information does not exist to ascertain whether NK_2_ receptor activation by neurokinin A, which can be a more potent bronchoconstrictor than substance P (Kraneveld et al., 2002), might be involved. Also, while substance P can stimulate mast cell degranulation and release of bronchoconstrictors such as histamine (Suzuki et al., 1995; Lilly et al., 1995), in vivo evidence of changes in mast cells was not identified. However, given the recruitment of other immune cells to the airways after formaldehyde exposure, an event that can be mediated by mast cells (Dawicki and Marshall, 2007), data on mast cells may represent critical information that is missing from the present analysis. Overall, based on the consistent moderate evidence for changes in the LRT that are commonly associated with changes in pulmonary function and airway responsiveness, this incomplete sequence of events is likely one of the mechanisms by which formaldehyde exposure could cause airway hyperresponsiveness and decreased pulmonary function. However, the pertinence of some or all of the components in this pathway with long-term, low-level formaldehyde exposure is unknown, and it is considered likely that other important mechanistic events would be identified with additional studies, particularly those testing longer exposure durations. It remains unclear how directly translatable this pathway, based largely on animal data, might be to interpreting complex human diseases such as asthma, and notable events thought to be important to the development or progression of asthma have not been observed.

##### 5) Allergic sensitization and airway hyperreactivity through altered antibody-related responses in the blood

[underlined: Interpretation]: It is unclear whether this is a possible mechanism by which formaldehyde inhalation could cause these effects, as an understanding of the potential mechanistic relationships is incomplete.

Many reactive oxygen and nitrogen species (ROS, RNS) can be essential immunomodulatory signaling molecules. However, prolonged, or excessive exposure to these factors can modify the structural and functional integrity of a wide range of cell and tissue types. Elevated indicators of oxidative stress have been identified in nearly all tissues examined following formaldehyde exposure, including the blood. In the blood of exposed humans, formaldehyde concentrations as low as 0.1 mg/m^3^ have been shown to cause lipid peroxidation in peripheral immune cells, typically with prolonged exposure. The data are not available to demonstrate what might be causing this increase in free radicals, although factors released into the circulation as a result of pronounced or sustained airway inflammation would be expected to be capable of causing such an effect. Specifically, regarding the elevated corticosterone levels, which have been reported in rats exposed for several weeks to much higher formaldehyde levels (3 mg/m^3^), an excess of glucocorticoids is typically associated with the inhibition of T cell cytokine secretion and function, although they may more specifically enhance the Th2 lineage and suppress the Th1 lineage (Taves and Ashwell, 2020; Elenkov, 2004). However, the varied roles for stress hormones (and free radicals) in the regulation of immune responses are complex (Glaser and Kiecolt-Glaser, 2005). Formaldehyde-specific studies examining the dynamics of this potential interplay were not identified.

Immunomodulatory effects of circulating stress hormones (and free radicals) could plausibly be associated with changes in circulating immune cells. As previously mentioned, although formaldehyde-induced changes in circulating immune cells were consistently observed, they varied in magnitude and direction across studies, suggesting a complex regulatory mechanism(s) for these effects. For example, decreases in CD8^+^ T cells were primarily observed in the blood of individuals exposed to higher levels of formaldehyde (>0.5 mg/m^3^), but not in studies testing lower exposure levels for comparable durations. CD8^+^ T cells are composed of five subpopulations with numerous roles for both cell-mediated immunity and Th2-mediated allergies (Mittrücker et al., 2014). However, the majority of formaldehyde-specific studies evaluating T cell responses did not distinguish subpopulations of CD4^+^ or CD8^+^ T cells, since a number of these subpopulations have only recently been discovered, and some studies only assessed total T cells (see Table C-35). This complicates interpretations of these responses and raises the possibility that more consistency in changes across studies may exist for specific T cell subpopulations. Perhaps more importantly, the evidence for changes in CD4^+^ T cells, which would be highly informative to this analysis as they are viewed as critical to the development of hypersensitivity (Cohn et al., 2004), was mixed and uninterpretable. Stimulated CD8^+^ T cells produce IFN-γ, providing a plausible linkage between the decreases in CD8^+^ T cells and the decrease in IFN-γ at >0.75 mg/m^3^ formaldehyde in several studies. The observed increase in IL-4 at similar formaldehyde levels is more complicated, as its regulation is tightly controlled and likely to be mediated by multiple mechanisms. B cell proliferation and production of IgE and certain IgG subtypes is dependent on IL-4 and inhibited by IFN-γ (Paul et al., 1987), providing support for a relationship between these cytokine changes and altered IgG-related responses. The evidence of alterations in the number of B cells, as well as the potential relationship between B cell levels and Ig levels, would benefit from additional study.

Understanding the regulation and function of IgE and IgG responses continues to evolve. IgE has a clear role in the development of allergic diseases that affect the airways, including allergic asthma, although IgE may not always be essential (e.g., in other types of asthma; in other allergic disorders). In contrast, IgG responses are poorly understood. While IgG may help to exacerbate IgE responses (e.g., patients with increases in both IgE and IgG are at greatest risk for developing allergic responses) and IgGs alone might induce allergic reactions to certain antigens (Wu and Zarrin, 2014; Williams et al., 2012; Finkelman, 2007), an excess of IgG antibodies can prevent IgE-mediated hypersensitivity and persons with increases in IgG alone are not typically at increased risk for allergic-related responses (Williams et al., 2012; Strait et al., 2006; Pandey, 2013). The evidence from formaldehyde-specific studies is insufficient to clarify whether IgE-mediated responses are involved (i.e., the evidence was considered slight, and was generally mixed and inconclusive), nor is it clear that changes in IgG are related to the development of sensitization or airway hyperresponsiveness. Further clarification of the observed IgG changes is also necessary, as some of the changes noted in response to formaldehyde exposure may depend on the duration of exposure or the specific IgG subtype examined. The antibody-related responses discussed herein have only been measured in the blood, as compared to samples that might be more directly informative to immune responses in the airways (e.g., nasal lavage or BAL). This is a notable data gap, given the somewhat disparate findings regarding immune cell counts in the airways and the blood. Overall, there are still critical uncertainties in the formaldehyde-specific antibody data.

In typical allergic disorders, changes in CD4^+^ Th2 cells are present and are thought to play a prominent role, whereas CD8^+^ T cell responses are generally lacking. Similarly, although IgG might contribute to allergic sensitization, the prototypical antibody response in allergy is thought to be largely driven by IgE. While it is possible that formaldehyde exposure may cause sensitization-related responses through a predominant IgG response rather than through IgE, the data demonstrating or proving such a linkage are not currently available. Overall, the available formaldehyde-specific studies do not provide information sufficient to disentangle the complex interplay between CD4^+^ and CD8^+^ T cells and B cells, regulatory cytokines such as IL-4, and the IgG and IgE responses that might underly the potential for formaldehyde to induce the interrelated immune effects of allergic sensitization and airway hyperresponsiveness.

Overall, the potential sequence(s) of events that may underly the observed changes in circulating antibodies remains poorly defined. Further, although a linkage between IgG responses and hypersensitivity is plausible, additional clarification is needed regarding the potential role for these types of changes in the pathogenesis of airway disease. Thus, based largely on an incomplete understanding of the necessity and ability of changes in IgG to induce these responses, and a lack of convincing formaldehyde-specific evidence demonstrating changes in IgE, it is unclear whether this is a possible mechanism by which formaldehyde exposure might cause these immune effects.

##### 6) Airway hyperresponsiveness and allergic sensitization through airway eosinophilia and/or sustained airway inflammation

[underlined: Interpretation]: This is a likely a mechanism by which formaldehyde inhalation could cause airway hyperresponsiveness in those sensitized to allergens, although additional unidentified events are expected to contribute. It is also a possible mechanism by which formaldehyde inhalation could cause airway hyperresponsiveness in nonsensitized individuals. Whether this mechanism is useful for explaining the development of allergic sensitization is unclear.

A number of studies demonstrate that short-term formaldehyde exposure, and possibly longer-term exposure (the data are sparse), can cause an increase in eosinophils in both the upper and lower airways, particularly in animals sensitized to allergens. As previously mentioned, an understanding of how this recruitment occurs remains unclear. Although specific events proving a linkage have not been demonstrated, other formaldehyde-specific observations may be associated with this change. For example, airway epithelial cells, which are modified as a result of formaldehyde exposure, can release immuno-stimulatory factors, including the Th2 cytokines, IL-4 and IL-13, when exposed to allergens (Li et al., 1999). While changes in IL-4 have been noted in the LRT and could plausibly be related to altered epithelial cells mediating recruitment of eosinophils, the more important, and thus more convincing, evidence of such a linkage would involve increases in IL-3, IL-5, IL-13, GM-CSF, and/or eotaxin (Wang et al., 2007a; Trivedi and Lloyd, 2007; Jacobsen et al., 2014); however, the formaldehyde-specific evidence related to these latter factors is limited and generally inconsistent. Alternatively, eosinophil recruitment could be related to increased neuropeptide release from stimulated sensory nerve endings, as previously discussed. Bidirectional communication exists between sensory nerve endings and immune cells of the airways, and neuropeptide release can be enhanced by various cytokines and neurotrophins, including nerve growth factor (NGF) (Nockher and Renz, 2006). NGF, which can also induce mast cell degranulation and shift T cells towards a Th2 response (Mostafa, 2009; de Vries et al., 2001) and drive antigen-induced and tachykinin-mediated increases in inflammatory cells such as eosinophils (Quarcoo et al., 2004), may also be modified in the airways following formaldehyde exposure (Fujimaki et al., 2004b) (not shown in Figures C-23 and C-24). Specifically, regarding eosinophils, released neuropeptides such as substance P have been shown to prime eosinophils for chemotaxis by other factors such as leukotrienes or IL-5, and these neuropeptides can induce accumulated eosinophils to release factors associated with cellular activation, such as eosinophil cationic protein (Kraneveld and Nijkamp, 2001). Similar to the lack of evidence supporting a linkage with altered epithelial cell function, formaldehyde-specific data are not available to inform such potential linkages. Indirectly, neuropeptide release could also be associated with facilitating the recruitment of eosinophils to the airway by increasing the permeability of the microvasculature, although this evidence still fails to identify the immuno-attractant stimuli. Given the gaps in these linkages, it is likely that this sequence of events is incomplete. Of specific note, evidence of changes in CD4^+^ Th2 cells in the LRT would be expected for each of these potential scenarios leading to eosinophil recruitment, as these cells release factors such as IL-5 and are known to aid eosinophil recruitment in multiple experimental scenarios (Trivedi and Lloyd, 2007; Hogan et al., 1998).

Regardless of the mechanism of recruitment, the evidence indicates that airway eosinophils are increased by formaldehyde exposure, and activated eosinophils are known to affect airway contractile responses. Thus, even a short-lived increase in eosinophils could increase bronchoconstriction (e.g., through the release of mediators such as leukotrienes, major basic protein and M2 receptor antagonists, and through the activation of other immune cells such as mast cells and basophils, all of which can act on smooth muscle). However, the relationship of increased eosinophils to airway hyperresponsiveness or allergic sensitization to nonspecific stimuli is more complicated and depends on a combination of factors, many of which the formaldehyde-specific data do not address. For example, the longevity of this eosinophilic response following formaldehyde exposure, particularly in healthy individuals, remains unclear. Short-term eosinophil effects on pulmonary function with subsequent clearance of these cells from the airways would be unlikely to lead to prolonged hypersensitivity of the airways, which would be expected to involve persistent activation of these cells and continued production of pro-inflammatory mediators. A single animal study suggests that eosinophils persist with subchronic formaldehyde exposure at 2.3 mg/m^3^ (but not at ≤0.5 mg/m^3^) in animals sensitized to allergen (Fujimaki et al., 2004b), and other indirect evidence indicates that inflammation of the airways persists with long term formaldehyde exposure, particularly in those sensitized to allergens (see Appendix C.7.2). However, it remains unknown whether these latter findings reflect the involvement of the populations of immune cells and secreted factors believed to be critical to the development of airway hyperresponsiveness. As previously described, the evidence examining the involvement of other important immunomodulatory events expected to affect airway responsiveness and allergic sensitization, including activation of basophils and mast cells, recruitment and/or development of a Th2 phenotype in CD4^+^ T cells, evidence of remodeling^21^ in the bronchi and/or alveoli, and changes in secreted factors known to affect smooth muscle reactivity, is generally slight or inadequate. These represent important data gaps.

Some experimental animal studies also report data suggesting increases in CD8^+^ T cells in the LRT at very high levels of formaldehyde (>5 mg/m^3^) with short term exposure. Similar to the observed LRT increases in eosinophils, the mechanism(s) mediating this recruitment to the airways is unknown, but likely to be downstream of formaldehyde-induced changes to epithelial cells and/or sensory nerve fibers. The observation of this change alongside the moderate evidence of decreases in CD8^+^ T cells in the blood, generally suggesting a threshold for this effect around 0.5 mg/m^3^, is of interest (note: similar trends in changes in other cells populations, including NK cells, were also observed). Recruitment of lymphocytes to inflamed airways from the blood in response to acute insults is assumed for multiple respiratory disorders (Medoff et al., 2005) and has been demonstrated with different pathogenic stimuli, including exacerbation of asthma or COPD by rhinovirus infection (Message et al., 2008; Mallia et al., 2014). In these models, rhinovirus challenge generally causes an increase in BAL cells, including eosinophils and CD8^+^ lymphocytes (and possibly neutrophils), while cell counts in the blood, including CD4^+^ and CD8^+^ T cells (and possibly NK cells) are decreased. In these types of studies, the specific relationship and magnitude of these changes appears to depend on the “dose” (e.g., viral load), as well as the sequence of pathology (e.g., viral challenge in symptomatic individuals). While the exact mechanisms underlying these complementary changes are unclear, hypotheses include modifications to epithelial cell function that leads to exaggerated immune responses in the absence of cytotoxicity (Proud and Leigh, 2011; Gavala et al., 2013). Thus, some of the observed airway inflammatory responses could be mediated through a sequence of events resulting from recruitment of certain immune cell populations from the blood to the airways, which may be directly relevant to changes observed in acutely challenged humans with airway disorders.

Overall, the evidence for persistent increases in airway immune cells and other immunomodulatory factors following formaldehyde exposure in individuals with prior allergen sensitization is interpreted as likely to represent an incomplete mechanism that could lead to airway hyperresponsiveness, as relevant observations have been reported after long-term exposure. However, the currently available data are insufficient to indicate this sequence of events as a likely mechanism for airway hyperresponsiveness in nonsensitized individuals. Owing to the lack of reliable formaldehyde-specific evidence demonstrating changes in IgE and other immunomodulatory factors assumed to be essential to the development of allergic responses, it is unclear whether this is a possible mechanism by which formaldehyde might cause allergic sensitization. Similarly, it remains unclear how useful this pathway might be to interpreting complex human diseases such as asthma. Additional studies are needed, particularly those employing long-term, low-level formaldehyde exposure.

#### Consideration of mechanistic pathways that may be associated with each potential respiratory system health effect

Several conclusions are suggested by the analyses of potential mechanistic pathways that might be associated with individual respiratory health effects, based on the most reliable formaldehyde-specific data:

- The confidence in the suggested mechanistic associations varies across the respiratory system health effects. While some uncertainties remain, important mechanistic events associated with sensory irritation, squamous metaplasia, and to a lesser extent, decreased pulmonary function, are supported by robust or moderate formaldehyde-specific data, and the relationships described are largely well-understood biological phenomena or have been demonstrated following formaldehyde exposure. Comparatively, the understanding of mechanisms for potential immune effects is less complete. While moderate evidence exists for several mechanistic events that are likely to be involved in the development of airway hyperresponsiveness, the effect(s) at the point of contact that leads to these events is unclear. The mechanistic evidence describing the potential development of allergic sensitization is the most limited, as it includes slight evidence for several events, and the majority of the potential mechanistic relationships have not been experimentally validated and a clear scientific consensus regarding the relationships does not exist.
- The primary mechanism for sensory irritation is considered well understood, although it is based largely on acute or short-term exposures, and sensitivity is expected to vary between individuals. While studies clarifying the effects of tissue modification with longer term exposure in humans would be useful, it is likely that rodents exposed to ≈0.2 mg/m^3^ formaldehyde under normal conditions would exhibit this effect. However, as exposure to formaldehyde appears to cause airway inflammation, which can increase the sensitivity and response magnitude of sensory nerve fibers, inflammation is viewed as a likely modifier of sensory irritation.
- At least one of the mechanisms by which formaldehyde exposure could cause squamous metaplasia is considered well understood, and it appears to depend on both exposure level and duration. Based on the pathway presented, these events are likely to occur at similar or slightly higher formaldehyde levels than those causing sensory irritation, and while cumulative tissue modifications with longer exposure or differences in human anatomy may increase sensitivity, the available experimental animal evidence suggests that pronounced effects leading to metaplasia are unlikely below 0.5 mg/m^3^.
- Several contributing mechanistic pathways appear to impact pulmonary function, and the complex interactions within and across these pathways are expected to involve additional, unidentified factors. While some important mechanistic changes occur at low formaldehyde exposure levels (e.g., ≤0.2 mg/m^3^ in rodents), data are not available to quantitatively relate these changes to decrements in pulmonary function. In addition, sensitivity is expected to be influenced by the respiratory health of exposed individuals. As with the mechanistic evidence supporting other health effects, much of the data is based on short term exposure. As exposure duration increases, and in the absence of potential compensatory mechanisms (which remains largely unexamined), amplification of these mechanistic events is expected.
- Given the lack of clear explanatory mechanisms for allergic sensitization, in particular, and uncertainties in data that may help to explain airway hyperresponsiveness, as well as an expectation of a large amount of important information that has not yet been identified in formaldehyde-specific studies, it is difficult to speculate on the exposure level- and duration-dependence of these potential pathways. However, some of the important events that may be involved (e.g., eosinophil increases) suggest a duration-dependence for the development of persistent changes in the sensitivity of the airways (note: transient hyperresponsiveness may be possible with short-term exposure), while other important data suggest that a concentration threshold likely exists in regard to critical changes in the cellular immune responses. Individual variability, including underlying respiratory health, is expected to be a significant modifier of these effects.

## C.8 CANCER (SUPPORTING INFORMATION FOR HAZARD)

### C.8.1 Cancers other than Upper Respiratory Tract and LHP Cancers

Cancer sites for which data were reported that were not formally reviewed in this assessment included lung, non-Hodgkin lymphoma, brain, bladder, colon, pancreas, prostate, and skin cancers (see Section 2.2.9 of the Toxicological Review). A summary of the studies available on lung, non-Hodgkin lymphoma, and brain are provided below for information. The data on bladder, colon, pancreas, prostate, and skin cancers were sparse and, as such, these studies are not summarized.

#### Lung Cancer

Evidence describing an association between formaldehyde exposure and the risk of dying from lung cancer is available from 31 epidemiologic studies (Walrath and Fraumeni, 1983; Walrath and Jr, 1983; Walrath and Fraumeni, 1984; Stroup et al., 1986; Stern, 2003; Stellman et al., 1998; Solet et al., 1989; Robinson et al., 1987; Partanen et al., 1990; Meyers et al., 2013; Marsh et al., 2001; Logue et al., 1986; Liebling et al., 1984; Levine et al., 1984b; Jakobsson et al., 1997; Hayes et al., 1990; Hansen and Olsen, 1995; Gérin et al., 1989; Edling et al., 1987b; Divine and Barron, 1987; Dell and Teta, 1995; De Stefani et al., 2005; Coggon et al., 2014; Chiazze et al., 1997; Checkoway et al., 2011; Bond et al., 1986; Blair et al., 1990; Bertazzi et al., 1986; Bertazzi et al., 1989; Beane Freeman et al., 2013; Band et al., 1997; Andjelkovich et al., 1995). Currently, these are the only primary studies that provide informative evidence of the effect of formaldehyde exposure on the risk of dying from lung cancer. A few studies are interpreted as unlikely to be informative (i.e.(Wesseling et al., 1996; Harrington and Oakes, 1984; Hansen et al., 1994; Hall et al., 1991; Fryzek et al., 2005)), based on considerations used to evaluate observational studies in the toxicological review.

#### Non-Hodgkin Lymphoma

The most specific level of non-Hodgkin lymphoma diagnosis that is commonly reported across the epidemiologic literature has been based on the first three digits of the Eighth or Ninth Revision of the ICD code [i.e., non-Hodgkin lymphoma ICD-8 and ICD-9: Codes 200 and 202 (WHO, 1967, 1977); however, early studies reported results for lymphosarcoma/reticulosarcoma alone (ICD-8/9: Code 200)]. Evidence describing the association between formaldehyde exposure and the specific risk of non-Hodgkin lymphoma was available from 19 epidemiologic studies—four case-control studies (Wang et al., 2009b; Tranah et al., 2009; Gérin et al., 1989; Blair et al., 1993) and 15 cohort studies (Walrath and Fraumeni, 1983; Walrath and Jr, 1983; Walrath and Fraumeni, 1984; Stroup et al., 1986; Stellman et al., 1998; Robinson et al., 1987; Meyers et al., 2013; Matanoski, 1989; Hayes et al., 1990; Hansen and Olsen, 1995; Edling et al., 1987b; Dell and Teta, 1995; Coggon et al., 2014; Beane Freeman et al., 2009; Band et al., 1997; Andjelkovich et al., 1995). One study was interpreted as unlikely to be informative (i.e., (Matanoski, 1989)).

#### Brain Cancer

Evidence describing an association between formaldehyde exposure and the risk of dying from brain cancer is available from 17 epidemiologic studies (Walrath and Fraumeni, 1983; Walrath and Jr, 1983; Walrath and Fraumeni, 1984; Stroup et al., 1986; Stellman et al., 1998; Robinson et al., 1987; Meyers et al., 2013; Matanoski, 1989; Levine et al., 1984b; Hayes et al., 1990; Hauptmann et al., 2009; Hansen and Olsen, 1995; Hagmar et al., 1986; Dell and Teta, 1995; Coggon et al., 2003; Beane Freeman et al., 2013; Band et al., 1997; Andjelkovich et al., 1995). Currently, these are the only primary studies that provide evidence of the effect of formaldehyde exposure on the risk of dying from brain cancer. A few studies were interpreted as unlikely to be informative (i.e., (Wesseling et al., 1996; Harrington and Oakes, 1984; Hansen et al., 1994; Hall et al., 1991)).

3 During a typical DNA extraction of tissue homogenates, the DNA separated into aqueous phase is termed aqueous (AQ) DNA, while the DNA trapped in the protein precipitate from the interphase (between aqueous and organic phases) was washed, treated with protein kinase and reextracted to get the interfacial DNA (IF DNA).

4 Heck et al. (1985) air concentration = 1.9 ppm (2.34 mg/m^3^); t = 40/60 h; Inhalation Rate = 10–15 cubic m/day. Assuming 10 m^3^/24 hours, we get 10/24 m^3^/h. Formaldehyde inhaled = 1.9 × 1.23 × (10/24) × 40/60 h = 0.649 mg. Body water = 40 kg for a 70-kg man (Guyton, 1991); concentration of HCHO = HCHO inhaled/body water in mg/kg = 0.649/40 = 0.0162 mg/kg or µg/g.

5 Even if one were to assume that formaldehyde stays only in the blood stream, this concentration increases to 0.12 μg/g of blood, which is still within the experimental error.

6 The acac method entails the cyclization of 2, 4-pentanedione (acac), ammonium acetate, and formaldehyde to form dihydropyridine 3, 5-diacetyl-1, 4-dihydrolutidine (DDL), which fluoresces at 510 nm after excitation at 412 nm.

7 This strain of the rat is considered anatomically representative of its species and widely used experimentally, most notably in bioassays sponsored by the National Toxicology Program.

8 Such idealized representations are likely to be inappropriate for considering susceptible individuals, such as those with chronic obstructive pulmonary disease.

9 Note: the oronasal switch occurs at about 35 L/min (Niinimaa et al., 1981).

10 Mouth breathers form a large segment of the population. Furthermore, at concentrations of formaldehyde where either odor or sensory irritation becomes a significant factor, humans are likely to switch to mouth breathing even at resting inspiration. (Overton et al., 2001) did not model uptake in the oral cavity at minute volumes less than 50 L/min. However, since 0.55 of the inspired fraction is through the mouth for the normal nasal breathing population (Niinimaa et al., 1981) at an inspiratory rate of 50 L/min, we can make an indirect inference from their result at this heavy breathing rate that average flux across the human mouth lining would be comparable to the average flux across the nasal lining computed in (Kimbell et al., 2001b; Kimbell and Subramaniam, 2001) for mouth breathing conditions at resting or light exercise inspiratory rates.

11 This 1993 CFD model differed somewhat from the subsequent model by (Kimbell et al., 2001b) used in this assessment. In the 1993 model, the limiting mass-transfer resistance for the gas was assumed to be in the air phase; that is, the concentration of formaldehyde was set to zero at the airway lining. Furthermore, this same boundary condition was used on the nasal vestibule as well, while in the more recent model, the vestibule was considered to be nonabsorbing. Unfortunately, (Kimbell et al., 2001b) did not report on correspondences between flux patterns and lesion distribution.

12 Several studies cited in Tables C-12 and C-13 tested formalin, which means the animals were co-exposed to formaldehyde and methanol. Considering that methanol’s mouse RD_50_ of 54,963 mg/m^3^ (41,514 ppm) is 10,000 times greater than formaldehyde’s mouse RD_50_, methanol was likely to have a negligible impact on the formaldehyde RD values (Nielsen et al., 2007).

13 https://www3.epa.gov/pesticides/chem_search/cleared_reviews/csr_PC-128831_13-Feb-01_b.pdf.

14 Studies that used formalin often contained 10–15% methanol as a stabilizing agent. Although formaldehyde is a metabolic product of methanol, it is not genotoxic in in vitro reactions.

15 For example, although only indirectly applicable to formaldehyde exposure-induced sensory irritation, dry eye disease is far more prevalent in older individuals (age 50+) than younger individuals (under 18) (Farrand et al., 2017). This is based, at least in part, on differences in tissue physiology that help regulate access of airborne irritants to sensitive components of the eye (e.g., reduced tear production and changes in lipid composition with aging). While this may also apply to the direct irritant effects of airborne formaldehyde on the eye, it is unclear the extent to which parallel, protective, age-dependent mechanisms exist within the nasal epithelium.

16 These data from Meng et al. are revisited in the context of uncertainty and variability in the dose-response for cell replication in Appendix D.2.2.

17 Note: neural reflexes involving afferent and efferent activity of the vagus nerve (e.g., across different LRT regions), some of which may involve C fibers and TRP channels, are better established (Mazzone and Undem, 2016).

18 Several studies examining the lineage and maturity of immune and non-immune cells in the bone marrow and other systemic tissues (e.g., blood; spleen) are not discussed in this section. Although it is possible that differences in the maturation phenotype of cells could indirectly contribute to the immune changes of interest to this section, such alterations would be expected to cause functional or other detectable changes in more apical mechanistic events relevant to immune responses in the respiratory system. Thus, this discussion focuses on those mechanistic events considered more directly relevant to these POE outcomes. Please see Section 3.3.3 of the Toxicological Review for a discussion of these cell lineage and maturation markers in the context of lymphohematopoietic cancer MOA.

19 Controlled human exposure studies observed pulmonary function deficits when a longer exercise component (15 minutes) was included. These deficits were not observed by other studies with shorter periods or no exercise (Green et al., 1987; Green et al., 1989), and another study observed airway hyperresponsiveness with an exposure protocol using nose clips requiring mouth-only breathing (Casset et al., 2006).

20 This approach draws some parallels to the AOP conceptual framework approach (Villeneuve et al., 2014; Ankley et al., 2010). As such, for those familiar with AOP terminology, it may be useful to think of the terms used herein according to related AOP terms (e.g., “plausible initial effects of exposure” and “initial alterations” relate to “molecular initiating events”; “mechanistic events” relate to “key events”; and “key hazard features” relate to “adverse outcomes”).

21 “Airway remodeling” has a specific meaning in human airway disease (see (Bergeron and Boulet, 2006)). Several formaldehyde-specific animal studies defined the observed airway structural changes as remodeling (e.g., (Wu et al., 2013; Qiao et al., 2009; Liu et al., 2011)). Although the studies’ data may relate to some aspects of airway remodeling, they are more generally described herein as inflammatory histologic changes to avoid misinterpretation.