# APPENDIX B SYSTEMATIC REVIEW METHODS DOCUMENTATION

## B.1 SUMMARY OF DOCUMENTATION

This Appendix complements the methods outlined in Sections 2.2 and 2.3 of the Toxicological Review, namely the literature search and screening and the study evaluation portions of the assessment, respectively. This Appendix provides the documentation of applying those methods to the formaldehyde inhalation evidence base for literature search and screening (Appendix B.2) and study evaluation (Appendix B.3). For this assessment, the searches and study evaluations were specific to each health effect- or mechanism- specific topic, as described in Section 2 of the Toxicological Review. Thus, although there is overlap (e.g., for epidemiology studies or experimental animal studies irrespective of health topic), they are documented separately by topic.

This Appendix also includes the results of a systematic evidence map (SEM) developed in 2021 (see Section 2.2 of the Toxicological Review). The results of that SEM are similarly subdivided by health effect- or mechanisms-specific topic. The specific aims of the 2021 SEM were: to:

- Identify epidemiological (i.e., human), toxicological (i.e., experimental animal), and mechanistic literature using an identical literature search approach as was used to develop a 2017 Step 1 draft IRIS formaldehyde-inhalation assessment (see Section 2.2).
- Tag supplemental (not primary research) studies.
- Create a literature inventory of studies meeting PECO criteria. The literature inventory summarizes basic features of study design, health system(s), and endpoints assessed.
- Assess PECO-relevant studies, within each health effect category, to determine if they are possibly impactful (i.e., likely, based on the study design and tested exposure levels, to have a potential impact on the hazard conclusions or toxicity values), and document the reasons in a literature inventory.

## B.2 LITERATURE SEARCH AND SCREENING

### B.2.1 Overview

As described in Section 2.2.1 of the Toxicological Review, initial searches (computerized searches augmented by secondary search approaches) were conducted in 2012, except for the search for mechanisms related to respiratory health effects, (Appendix B.2.6), which was initially conducted in 2014. Annual updates were performed annually through 2016 in support of development of a completed, 2017 draft assessment. In 2021, a separate systematic evidence map (SEM) was developed to identify the relevant literature from 2016 through 2021, in particular studies with the potential to impact hazard or toxicity value conclusions. Thus, Appendix B.2.2 through B.2.10 below separately describes the search strings used, the search and screening results for literature searches through 2016, and the literature search results and documentation of the screening from the 2021 SEM. Details of the methods are provided in the corresponding subsections of Section 2.2 in the Toxicological Review.

The literature search results and tagging (i.e., the screening decisions by the two reviewers based on the PECO criteria in the Toxicological Review) are separately documented in HERO (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/4051).^1^

### B.2.2 Sensory Irritation

As detailed in Section 2.2.2 of the Toxicological Review, the sensory irritation review focused on human studies of symptoms of irritation, primarily ocular, nasal, and throat symptoms. Animal and mechanistic studies were not a focus of this search. The search strings are documented in Table B-1, the literature search results through 2016 are documented in Figure B-1, and the literature search results through 2021 identified by the SEM are documented in Figure B-2, with the SEM screening decisions documented in the subsequent section.

#### Search Strings

Table B-1 Search terms for sensory irritation

Database, search parameters | Terms
PubMed; No date restriction | (Formaldehyde[majr] OR paraformaldehyde[majr] OR formalin[majr]) AND (irritation OR irritant OR irritants)
Web of Science; No date restriction | TS= (Formaldehyde OR paraformaldehyde OR formalin) AND TS=(irritation OR irritant OR irritants)

#### Literature Search Results through 2016

Figure B-1 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and sensory irritation in humans

#### Literature Search Results from the Systematic Evidence Map Update through 2021

Figure B-2 Sensory irritation literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Sensory_irritation/))

A total of 121 citations were retrieved for the assessment of sensory irritation in humans and five studies met PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

Of the five studies meeting PECO criteria, one of the identified studies was deemed to be possibly impactful (Saowakon et al., 2015) but already had been included in the 2017 draft (Table B-2), and thus zero additional studies were included.

Table B-2 Studies of sensory irritation effects in humans

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Humans
Saowakon et al. (2015) | Not extracted | Not extracted | Not extracted | Possibly impactful | Already identified and considered in 2017 draft
Aung et al. (2021) | Occupational Myanmar; cross-sectional | Air sampling, adults, medical students, and instructors in anatomy dissection rooms | Unpleasant odor, eye irritation, nasal irritation symptoms | Not impactful | High exposure levels, adults, health effects well-established
Deng et al. (2020) only abstract available (full text Chinese) | Occupational China; cross-sectional | Air sampling, adults, medical students in anatomy dissection rooms | Subjective symptoms (e.g., itchy eyes, nasal congestion, runny nose) | Not impactful | High exposure levels, adults, health effects well-established
Sakellaris et al. (2020) | Occupational Europe (Portugal, Spain, Italy, Greece, France, Hungary, the Netherlands, Finland); cross-sectional | Air sampling, adults, office building occupants | Eye irritation (dry eyes, watering, or itchy eyes, burning or irritated eyes), respiratory symptoms (blocked or stuffy nose, runny nose, dry/irritated throat, cough | Not impactful | Adults, health effects wellestablished
Thetkathuek et al. (2016) | Occupational, Chacheongsao Province, Thailand; cross-sectional | Air sampling, adults, medium-density fiberboard furniture workers | Respiratory irritation symptoms | Not impactful | High exposure levels, adults, health effects well-established

Rows for studies judged as “not impactful” are shaded gray.

### B.2.3 Pulmonary Function

As detailed in Section 2.2.3 of the Toxicological Review, the pulmonary function review focused on human studies of standard, quantitative pulmonary function measures, including spirometric measures, FEV_1_, FVC, and FEF_25_–_75_, as well as PEF measured using a flowmeter. Animal and mechanistic studies were not a focus of this search. The search strings are documented in Table B-3, the literature search results through 2016 are documented in Figure B-3, and the literature search results through 2021 identified by the SEM are documented in Figure B-4, with the SEM screening decisions documented in the subsequent section.

#### Search Strings

Table B-3 Summary of search terms for pulmonary function

Database, search parameters | Terms
PubMed; No date restriction | (Formaldehyde[majr] OR paraformaldehyde[majr] OR formalin[majr]) AND (“pulmonary function” OR “lung function” OR “spirometr*”)
Web of Science; No date restriction | TS=(Formaldehyde OR paraformaldehyde OR formalin) AND TS=(pulmonary function OR lung function OR spirometry)

Abbreviations: Majr= major topic (filter); TS= the requested “topic” is included as a field tag.

#### Literature Search Results through 2016

Figure B-3 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and pulmonary function in humans

#### Literature Search Results from the Systematic Evidence Map Update through 2021

Figure B-4 Pulmonary function effects in humans literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Pulmonary-function/))

A total of 30 citations were retrieved for the assessment of pulmonary function effects in humans and six studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

Of the six studies meeting the PECO criteria, one study, (Saowakon et al., 2015), was deemed to be possibly impactful (see Table B-4), but already had been included in the 2017 draft; thus, zero (0) additional studies were included.

Table B-4 Studies of pulmonary function effects in humans

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Humans
Saowakon et al. (2015) | Not extracted | | | Possibly impactful | Already identified and considered in 2017 draft
Fsadni et al. (2018) | Schools-based Malta; cross-sectional | Air sampling, children, school children | Pulmonary function tests (not specified) | Not impactful | Important details were not provided
Asgedom et al. (2019) | Occupational Ethiopia; cross-sectional | Air sampling, adults, particleboard workers | Lung function (FVC, FEV1, FEF 25-75%) | Not impactful | High exposure levels, adults
Deng et al. (2020) only abstract evaluated (full text Chinese) | Occupational China; cross-sectional | Air sampling, adults, medical students in anatomy dissection rooms | FEV1, FEV1/FVC, PEF, FEF 25%-75%, MEF25%, FEF50%-75% | Not | High exposure levels, adults impactful
Neghab et al. (2017) | Occupational Shiraz, Iran; cross-sectional | Air sampling, adults, kitchen workers exposed to cooking fumes | VC, FVC, FEV1, PEF, FEV1/FVC, FEV1/VC | Not impactful | High exposure levels, adults
Zarei et al. (2017) | Occupational Tehran, Iran; cross-sectional | Air sampling, adults, foundry coremakers | FVC, FEV1, FEV1/FVC, peak expiratory flow (PEF), mid forced expiratory flow (FEF25-75%) | Not impactful | High exposure levels, adults

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

FEF_25-75%_ - mid forced expiratory flow, FEF_50-75%_ - forced expiratory flow_50-75%_, FEV_1_- Forced expiratory volume in one second, FVC – forced vital capacity, PEF - peak expiratory flow, MEF_25%_ - mean flow at 25%, VC -vital capacity.

### B.2.4 Immune-Mediated Conditions, including Allergies and Asthma

As detailed in Section 2.2.4 of the Toxicological Review, the immune-mediated conditions review focused on hypersensitivity (allergy) and on asthma. The searches ultimately used to support the evidence synthesis and integration decisions focused on identifying studies of exposed humans. Although experimental animal studies of hypersensitivity were initially included in searches through 2016 (the 2021 SEM did not include this search), given the conclusion that these studies were most appropriately reviewed as mechanistic information (see Section 3.2.3 of the Toxicological Review), these studies were tagged as potentially relevant supplemental material and considered as part of the overarching mechanistic evaluation documented in Appendix B.2.6 (note that these studies were also identified by the searches specific to that mechanistic evaluation). The search strings are documented in Table B-5, the literature search results through 2016 are documented in Figure B-5, and the literature search results through 2021 identified by the SEM are documented in Figure B-6, with the SEM screening decisions documented in the subsequent section.

#### Search Strings

Table B-5 Search terms – allergy-related conditions and asthma

Database, Initial search date | Terms
PubMed; 10/31/2012; No date restriction | formaldehyde and (asthma or wheeze or respiratory or allergy or immune or sensitization) NOT (“formalin test” OR “formaldehyde fixation” OR “formalin fixation” OR “formalin fixed” OR “formaldehyde fixed” OR “formalin-induced” OR “formalin-evoked”)
Web of Science; 11/5/2012; No date restriction | (TS=formaldehyde and TS=asthma) OR (TS=formaldehyde and TS=allergy) OR (TS=formaldehyde and TS=immune) OR (TS=formaldehyde and TS=respiratory) OR (TS=formaldehyde and TS=sensitization) OR (TS=formaldehyde and TS=wheeze)
Toxline; 11/2/2012; No date restriction | formaldehyde @AND @OR (immune allergy asthma respiratory wheeze sensitization)

#### Literature Search Results through 2016

Figure B-5 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and respiratory and immune-mediated conditions

[Note: animal mechanistic studies were ultimately used in the analysis described in Appendix B.2.6, so were tagged as supplemental for this search]

#### Literature Search Results from the Systematic Evidence Map Update through 2021

Figure B-6 Asthma and immune effects in humans literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Asthma/))

A total of 1,597 citations were retrieved for the assessment of asthma and immune effects in humans and 16 studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

Of the 16 studies meeting PECO criteria, 11 studies were deemed to be possibly impactful (see Table B-6).

Table B-6 Studies of immune-mediated conditions in humans, focusing on allergies and asthma

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Humans
Branco et al. (2020a) | School-based Northern Portugal cross-sectional | Air sampling, children, preschoolers/primary school students | Asthma (reported, diagnosed), wheezing (active) | Possibly impactful | School-based – children; indoor formaldehyde concentrations between 10–80 µg/m^3^
Huang et al. (2017) | Population-based Shanghai, China case-control | Air sampling in residence, children | Current rhinitis | Possibly impactful | Population-based – children; indoor formaldehyde concentrations between 10–80 µg/m^3^
Isa et al. (2020a) | School-based Selangor, Malaysia cross-sectional | Air sampling in classroom, children | Rhinitis (past 12 months), skin allergy (past 12 months) | Possibly impactful | School-based – children; mean indoor formaldehyde concentrations between 10–80 µg/m^3^
Lajoie et al. (2014) | Population-based Quebec, Canada intervention study | Air sampling, children, ventilation intervention study | Change in prevalence of asthma symptoms and medical care | Possibly impactful | Population-based – children; mean indoor formaldehyde concentrations between 10–80 µg/m^3^
Li et al. (2019) | Population-based Hong Kong cohort | Air sampling, birth to 18 mo | Wheeze (new onset) | Possibly impactful | Population-based – children; mean indoor formaldehyde concentrations between 10–80 µg/m^3^
Liu et al. (2018a) | Population-based Changchun, China case-control | Air sampling in residence, children | Asthma diagnosis | Possibly impactful | Population-based – children; indoor formaldehyde concentrations between 10–80 µg/m^3^
Madureira et al. (2016) | Population-based Porto, Portugal case-control | Air sampling in residence, children | Current asthma | Possibly impactful | Population-based – children; indoor formaldehyde concentrations between 10–80 µg/m^3^
Neamtiu et al. (2019) | School-based Alba County, Romania cross-sectional | Air sampling in classroom, children | Asthma-like symptoms (difficult breathing, dry cough, wheezing in past week), allergy-like symptoms (skin conditions such as rash, itch, eczema; eye disorders such as red, dry, swollen, itching, burning, or sensation of “sand in eyes”; rhinitis such as itching nose, sneezes, stuffy or blocked nose) | Possibly impactful | School-based – children; mean indoor formaldehyde concentrations between 10–80 µg/m^3^
Norbäck et al. (2017) | School-based Johor Bahru, Malaysia cross-sectional | Air Sampling, children | Rhinitis | Possibly impactful | School-based – children; indoor formaldehyde concentrations between 10–80 µg/m^3^
Yon et al. (2019) | School-based Seongnam City, Korea cohort | Air sampling in classroom, children | Current asthma, rhinitis, rhinitis severity | Possibly impactful | School-based – children; mean indoor formaldehyde concentrations between 10–80 µg/m^3^
Yu et al. (2017) | Population-based Hong Kong cohort | Air sampling in residence, birth to 18 mo | Wheeze (new onset) | Possibly impactful | Population-based – children; mean indoor formaldehyde concentrations between 10–80 µg/m^3^
Asgedom et al. (2019) | Occupational Ethiopia cross-sectional | Air sampling, adults, particleboard workers | Respiratory symptoms (cough, cough with sputum production, phlegm, wheezing, shortness of breath) | Not impactful | Occupational exposure - adults
Dumas et al. (2020) | Occupational United States cohort | Occupational history and job-task-exposurematrix, adults, health workers (female nurses) | Self-reported incident physician-diagnosed asthma | Not impactful | Occupational exposure – adults
El-Feky et al. (2020) | Occupational Egypt cross-sectional | Industry/ production type, adults, factory workers | Chronic bronchitis, respiratory symptoms and signs, respiratory rate, nasal symptoms, eye symptoms, skin manifestations | Not impactful | Occupational exposure – adults
Fsadni et al. (2018) | School-based Malta cross-sectional | Air sampling in classroom, children | Wheezing, rhinitis, eczema, acoustic rhinometry, nasal lavage | Not impactful | Only qualitative results reported, e.g., whether statistically significant and directional arrow
Thetkathuek et al. (2016) | Occupational Chacheongsao Province, Thailand cross-sectional | Air sampling, adults, medium density fiberboard workers | Difficulty breathing, chest discomfort, wheeze | Not impactful | Occupational exposure - adults

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

### B.2.5 Respiratory Pathology

As detailed in Section 2.2.5 of the Toxicological Review, the respiratory tract pathology review focused on histopathological endpoints and signs of pathology in nasal and respiratory tissues. Separate searches were performed to identify studies in humans, focusing on evidence of pathology in nasal tissues, and in experimental animals, focusing on any respiratory tissue pathology. Signs such as changes in mucociliary function, cellular proliferation, mucus flow rate, and rhinitis were tracked as supplemental and included in the discussion of mechanistic information for respiratory effects (Appendix B.2.6). The search strings are documented in Table B-7 (human evidence) and Table B-8 (animal studies), the literature search results through 2016 are documented in Figure B-7 (human evidence) and Figure B-8 (animal studies), and the literature search results through 2021 identified by the SEM are documented in Figure B-9 (human studies) and B-10 (animal studies), with the SEM screening decisions documented in the subsequent sections.

#### Search Strings

##### Human Studies

Table B-7 Search terms for respiratory tract pathology in humans

Database, Initial Search Date | Terms
PubMed; 12/18/2012; No date limitation | (Formaldehyde[majr] OR paraformaldehyde[majr] OR formalin[majr]) AND (Hyperplasia OR metaplasia OR nasal mucosa OR occupational diseases OR respiratory tract diseases OR rhinitis OR mucociliary) AND (epidemiology OR epidemiological OR epidemiologic OR cohort OR retrospective studies OR retrospective OR prospective studies OR prospective OR cross-sectional OR case-control OR cross-sectional study OR prevalence study OR occupational)
Web of Science; 12/19/2012; No date limitation | TS= (Formaldehyde OR paraformaldehyde OR formalin) AND TS= (Hyperplasia OR metaplasia OR nasal mucosa OR occupational diseases OR respiratory tract diseases OR rhinitis OR mucociliary) and TS= (epidemiology OR epidemiological OR epidemiologic OR cohort OR retrospective studies OR retrospective OR prospective studies OR prospective OR cross-sectional OR case-control OR cross-sectional study OR prevalence study OR occupational)
Toxline; 05/03/2013; No date limitation | (Formaldehyde OR Paraformaldehyde OR Formalin) AND (Hyperplasia OR metaplasia OR nasal mucosa OR occupational diseases OR respiratory tract diseases OR rhinitis OR mucociliary) AND (epidemiology OR epidemiological OR epidemiologic OR cohort OR retrospective studies OR retrospective OR prospective studies OR prospective OR cross-sectional OR case-control OR cross-sectional study OR prevalence study OR occupational)

##### Animal Studies

Table B-8 Search terms for respiratory tract pathology in animals

Database, initial search date | Terms
PubMed; 10/18/2012; Search up through; 9/30/2012 | Formaldehyde* AND (animals OR dog OR dogs OR canine OR canines OR beagle OR beagles OR “guinea pig” OR “guinea pigs” OR Cavia OR hamster OR hamsters OR Cricetinae OR Mesocricetus OR mice OR mouse OR Mus OR monkey OR monkeys OR Macaca OR primate OR primates OR rabbit OR rabbits OR hare OR hares OR rat OR rats OR Rattus OR Rana or rodent OR rodents OR Rodentia) AND (alveol* OR bronchial OR bronchi OR buccal OR laryngeal OR larynx OR lung OR mouth OR nasal OR nasopharyngeal OR nasopharynx OR nose OR pharyngeal OR pharynx OR pulmonary OR respiratory OR sinonasal OR sinus OR trachea*) AND (edema OR oedema OR cancer OR carcinogens OR carcinogenesis OR carcinogenicity OR carcinoma OR “cell proliferation” OR cilia OR dysplas* OR epithelial OR epithelium OR goblet OR histopath* OR hyperplas* OR hypertrophy* OR metaplas* OR mucociliary OR mucos* OR mucous OR mucus OR necrosis OR neopla* OR olfactory OR patholog* OR rhinitis OR squamous OR transitional OR tumor OR tumour OR turbinate OR ulceration) NOT human
Web of Science; 10/18/2012; Search up through; 9/30/2012 | Topic=Formaldehyde* AND (animals OR dog OR dogs OR canine OR canines OR beagle OR beagles OR “guinea pig” OR “guinea pigs” OR Cavia OR hamster OR hamsters OR Cricetinae OR Mesocricetus OR mice OR mouse OR Mus OR monkey OR monkeys OR Macaca OR primate OR primates OR rabbit OR rabbits OR hare OR hares OR rat OR rats OR Rattus OR Rana or rodent OR rodents OR Rodentia) AND (alveol* OR bronchial OR bronchi OR buccal OR laryngeal OR larynx OR lung OR mouth OR nasal OR nasopharyngeal OR nasopharynx OR nose OR pharyngeal OR pharynx OR pulmonary OR respiratory OR sinonasal OR sinus OR trachea*) AND (edema OR oedema OR cancer OR carcinogens OR carcinogenesis OR carcinogenicity OR carcinoma OR “cell proliferation” OR cilia OR dysplas* OR epithelial OR epithelium OR goblet OR histopath* OR hyperplas* OR hypertrophy* OR metaplas* OR mucociliary OR mucos* OR mucous OR mucus OR necrosis OR neopla* OR olfactory OR patholog* OR rhinitis OR squamous OR transitional OR tumor OR tumour OR turbinate OR ulceration) NOT human
Toxline; 10/21/2012; Search up through; 9/30/2012 | formaldehyde AND (animal OR “nasal cavity” OR nose OR “respiratory tract” OR “cell proliferation” OR mucociliary OR histopathology OR pathology OR cancer OR tumor) NOT (human OR humans OR epidemiology OR epidemiological OR occupation* OR work* OR antinocicepti* OR nocicepti* OR pain OR sensory OR “formalin test” OR bacteria OR bacterial); (including synonyms and CAS numbers, but excluding PubMed records)

#### Literature Search Results through 2016

##### Human Studies

Figure B-7 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and respiratory tract pathology in humans

[Note: an additional controlled human exposure study that met PECO for the human respiratory tract pathology search (totaling 3) was identified by the sensory irritation search and evaluated (see Section B.3.5)].

##### Animal Studies

Figure B-8 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and respiratory tract pathology in animals

[Note: the MOA studies of cellular proliferation and mucociliary function were ultimately considered in study evaluation and thus tracked as meeting the PECO criteria, including ~10 of the MOA-only studies; other MOA studies were considered as Mechanistic information, see Section B.2.6].

#### Literature Search Results from the Systematic Evidence Map Update through 2021

##### Human Studies

Figure B-9 Human respiratory tract pathology literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Respiratory-tract-pathology-human/))

A total of 579 citations were retrieved for the assessment of respiratory tract pathology in humans and one study met the PECO criteria.

##### Animal Studies

Figure B-10 Animal respiratory tract pathology literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Respiratory-tract-pathology-animal/))

A total of 352 citations were retrieved for the assessment of respiratory tract pathology in animals and ten studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

##### Human Studies

This single human study meeting PECO criteria was deemed to be not impactful (see Table B-9); thus, zero additional studies were included.

Table B-9 Studies of respiratory tract pathology in humans

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Humans
Bruno et al. (2018) | Occupational Rome, Italy cross-sectional | Air sampling, adults, Laboratory pathology workers | Nasal cytology (muciparous metaplasia) | Not impactful | Adults, health effects well-established

Rows for studies judged as “not impactful” are shaded gray.

##### Animal Studies

Of the 10 animal studies meeting PECO criteria (see Table B-10), 1 (Morgan et al., 2017) was deemed to be possibly impactful. (Morgan et al., 2017) was identified in the literature search update and deemed to be possibly impactful, but already had been included in the 2017 draft; thus, zero (0) additional studies were included.

Table B-10 Animal studies of respiratory tract pathology

Reference | Study design | Exposure^a^ | Endpoints | Impactful? | Rationale
Animal Studies
Morgan et al. (2017) | Mouse (Trp53 haploinsufficient), Male Subchronic (8 wk; 6 hr/d, 5 d/wk), then held for 32 wk | Paraformaldehyde 0, 7.5 or 15 ppm (0, 9.2, 18.5 mg/m^3^) Inhalation | All major tissues and gross lesions were collected for histopathology (including squamous metaplasia in respiratory tissues) | Possibly impactful | Already included in 2017 draft
Aydemir et al. (2017) | Rat (Wistar), both sexes Subchronic (6 wk; 8 hr/d, 5 d/wk) | Formalin 0, 6 ppm (0, 7.38 mg/m^3^) Inhalation | Lung hematoxylin and eosin staining for qualitative review of inflammation and tissue morphology | Not impactful | Formalin; qualitative endpoints
Cheng et al. (2016) | Mouse (Kunming), male Short-term (up to 7 d; continuous) | Formalin 0, 0.08, 0.8 mg/m^3^ Inhalation | Hematoxylin and eosin staining for inflammation and edema | Not impactful | Formalin; primarily qualitative endpoints
Abreu et al. (2016) | Mouse (C57BL/6), both sexes Acute (8 hr) | Unspecified test article 0, 0.2, 1.0, 3.0 ppm (0, 0.25, 1.23, 3.69 mg/m^3^) Inhalation | Lung morphology and nasal ciliation; histological inflammatory cell counts in lung and scoring in nose | Not impactful | Unknown test article; acute
Lima et al. (2015) | Rat (Fischer), male Short-term (5 d; 20-min × 3/d) | Unspecified test article 0, 1, 5, 10% Inhalation | Trachea histology and morphometric analyses, including mucus production | Not impactful | Unknown test article; high levels; brief exposures
Liu et al. (2018b) | Rat (Sprague Dawley), male Short-term (4 wk; 8 hr/d) | Formalin 0, 0.5, 5, 10 mg/m^3^ Inhalation | Lung histopathological architecture measurements | Not impactful | Formalin
Payani et al. (2019) | Rat (Wistar), male Short-term (21 d; 1 hr/d) | Unspecified test article 0, 40% Inhalation (vapor) | Pulmonary histopathology | Not impactful | Unknown test article; high levels; brief exposures
Sapmaz et al. (2017) | Rat (Sprague Dawley), male Short-term (4 wk; 8 hr/d) or Subchronic (13 wk; 8 hr/d) | Paraformaldehyde 0, 5, 10 ppm (0, 6.2, 12.3 mg/m^3^) Inhalation | Hematoxylin and eosin staining (airway inflammation; morphology; scored injury); trachea thickness | Not impactful | High levels; primarily qualitative endpoints
Sholapuri et al. (2020) | Rat (Wistar), male Short-term (21 d; 1 hr/d) | Formalin 0, 40% Inhalation | Lung histopathology | Not impactful | Formalin; high levels; brief exposures
Song et al. (2017) | Mouse (Balb/c), male Short-term (18 d; 3 hr/d) | Formalin 0, 2.44 ppm (0, 3.00 mg/m^3^) Inhalation | Airway inflammation histology | Not impactful | Formalin; No formaldehyde-only control (without ovalbumin [OVA])

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

a Use of methanol-stabilized formalin was inferred in some studies based on study-specific description (e.g., 37% stock solution).

### B.2.6 Mechanistic Information Relevant to Noncancer Respiratory Effects

As detailed in Section 2.2.6 of the Toxicological Review, the searches for mechanistic information related to noncancer respiratory system effects included a specific focus on identifying studies relevant to potential inflammation- and immune-related changes. This search encompassed mechanistic information related to changes in the respiratory tract, blood, and lymphoid tissues that might not have been captured by health effect-specific systematic searches. As outlined in Section 2 of the Toxicological Review, the specific search strings below were augmented with studies identified as supplemental through other health effect-specific searches, including hypersensitivity-related responses in animal studies (see also Appendix B.2.4) and information on cellular proliferation and mucociliary function (see also Appendix B.2.5). The search strings are documented in Table B-11, the literature search results through 2016 are documented in Figure B-11, and the literature search results through 2021 identified by the SEM are documented in Figure B-12, with the SEM screening decisions documented in the subsequent section.

#### Search Strings

Table B-11 Summary of supplemental literature search terms for mechanistic studies relevant to potential noncancer respiratory health effects

Database | Search (no date limit thru 8/31/2014)
PubMed; searched 9/4/2014 | (*formaldehyde OR formalin) AND (“Adaptive immunity” OR asthma OR “atopic dermatitis” OR immune OR “innate immunity” OR redox OR allergic OR allergy OR “mucosal immunity” OR Eosinophil* OR Inflammation OR “Lung function test” OR “Nitric oxide” OR Wheezing OR rhinosinusitis OR lymphocyte OR bronchiolitis OR glucocorticoid OR IgE OR basophil OR “histamine-releasing factor” OR “mast cell” OR “reactive nitrogen species” OR “reactive oxygen species” OR “oxidative stress” OR isoprostane OR “Airway remodeling” OR phagocytosis OR “toll-like” OR “respiratory immunity” OR autoimmune OR interleukin OR “immune system” OR “allergic rhinitis” OR “chronic obstructive pulmonary disease” OR copd OR corticosteroids OR “Chronic bronchitis” OR fibrocyte OR hematopoie* OR “Epithelial injury” OR “epithelial repair” OR Th17 OR “Airway hyperresponsiveness” OR “Airway smooth muscle” OR “airway hyperreactivity” OR “Bronchoalveolar lavage” OR neutrophil OR cytokine OR Bronchiectasis OR th2 OR th9 OR “t cell” OR leukotriene OR “Bronchial epithelial cell” OR “Dendritic cell” OR Endothelin OR “growth factor” OR Lipoxins OR Prostaglandin OR cyclooxygenase OR “matrix metalloproteinase” OR ovalbumin OR “tumor necrosis factor” OR Phosphodiesterase OR “Bronchopulmonary dysplasia” OR Adipokine OR Eicosanoid OR bronchoconstriction OR Phospholipase OR Hyperpnoea OR bronchiectasis OR “corticosteroid responsiveness” OR “Type 2” OR “muscarinic receptor antagonism” OR “obstructive airway” OR Immunomodulation OR lipocalins OR allergen OR corticosteroids OR “Vascular endothelial growth factor” OR bronchiectasis OR immunodeficiency OR “Muscarinic receptor” OR *inflammatory OR Complement OR “Myeloid suppressor cell” OR immunoglobulin OR mucin OR Autophagy OR Leukocyte OR macrophage OR BALT OR “extracellular lining fluid”) NOT (nocicept* OR pain OR “formalin test” OR “formalin-induced” OR “formaldehyde-fixed” or “formalin-fixed” OR “paraformaldehyde-fixed” OR “formaldehyde fixation” OR “formalin fixation” OR “10% formalin” OR “10% buffered formalin” OR “10% neutral buffered formalin” OR vaccin* OR inactivated OR “formalin-killed” or “formaldehyde-killed” OR dental OR formalinized)
Web of Science; searched 9/5/2014 | (TS=(“formaldehyde” OR “formalin”) AND TS=(“Adaptive immunity” OR “asthma” OR “atopic dermatitis” OR “immune” OR “innate immunity” OR “redox” OR “allergic” OR “allergy” OR “mucosal immunity” OR Eosinophil* OR “Inflammation” OR “Lung function test” OR “Nitric oxide” OR “Wheezing” OR “rhinosinusitis” OR “lymphocyte” OR “bronchiolitis” OR “glucocorticoid” OR “IgE” OR “basophil” OR “histamine-releasing factor” OR “mast cell” OR “reactive nitrogen species” OR “reactive oxygen species” OR “oxidative stress” OR “isoprostane” OR “Airway remodeling” OR “phagocytosis” OR “toll-like” OR “respiratory immunity” OR “autoimmune” OR “interleukin” OR “immune system” OR “allergic rhinitis” OR “chronic obstructive pulmonary disease” OR “copd” OR “corticosteroids” OR “Chronic bronchitis” OR “fibrocyte” OR hematopoie* OR “Epithelial injury” OR “epithelial repair” OR “Th17” OR “Airway hyperresponsiveness” OR “Airway smooth muscle” OR “airway hyperreactivity” OR “Bronchoalveolar lavage” OR “neutrophil” OR “cytokine” OR “Bronchiectasis” OR “th2” OR “th9” OR “t cell” OR “leukotriene” OR “Bronchial epithelial cell” OR “Dendritic cell” OR “Endothelin” OR “growth factor” OR “Lipoxins” OR “Prostaglandin” OR “cyclooxygenase” OR “matrix metalloproteinase” OR “ovalbumin” OR “tumor necrosis factor” OR “Phosphodiesterase” OR “Bronchopulmonary dysplasia” OR “Adipokine” OR “Eicosanoid” OR “bronchoconstriction” OR “Phospholipase” OR “Hyperpnoea” OR “bronchiectasis” OR “corticosteroid responsiveness” OR “Type 2” OR “muscarinic receptor antagonism” OR “obstructive airway” OR “Immunomodulation” OR “lipocalins” OR “allergen” OR “corticosteroids” OR “Vascular endothelial growth factor” OR “bronchiectasis” OR “immunodeficiency” OR “Muscarinic receptor” OR *inflammatory OR “Complement” OR “Myeloid suppressor cell” OR “immunoglobulin” OR “mucin” OR “Autophagy” OR “Leukocyte” OR “macrophage” OR “BALT” OR “extracellular lining fluid”)) NOT TS=(nocicept* OR “pain” OR “formalin test” OR “formalin-induced” OR “formaldehyde-fixed” OR “formalin-fixed” OR “paraformaldehyde-fixed” OR “formaldehyde fixation” OR “formalin fixation” OR “10% formalin” OR “10% buffered formalin” OR “10% neutral buffered formalin” OR vaccin* OR “inactivated” OR “formalin-killed” or “formaldehyde-killed” OR “dental” OR “formalinized”) Indexes=SCI-EXPANDED, CPCI-S, BKCI-S, BKCI-SSH Timespan=All years
Toxline; searched 9/3/2014 | Part 1; @SYN0+@AND+(@OR+“Adaptive+immunity”+asthma+“atopic+dermatitis”+immune+“innate+im munity”+redox+allergic+allergy+“mucosal+immunity”+Eosinophil*+Inflammation+“Lung+function +test”+“Nitric+oxide”+Wheezing+rhinosinusitis+lymphocyte+bronchiolitis+glucocorticoid+IgE+bas ophil+“histamine-releasing+factor”+“mast+cell”+“reactive+nitrogen+species”+“oxidative+stress”+isoprostane+“Air way+remodeling”+phagocytosis+“toll-like”+“respiratory+immunity”+autoimmune+interleukin+“immune+system”+“allergic+rhinitis”+“c hronic+obstructive+pulmonary+disease”)+(@OR+formaldehyde+formalin+@term+@rn+50-00-0)+@NOT+(@OR+nocicept*+pain+“formalin+test”+“formalin-induced”+“formaldehyde-fixed”+“formalin-fixed”+“paraformaldehyde-fixed”+“formaldehyde+fixation”+“formalin+fixation”+“buffered+formalin”+“neutral+buffered+for malin”+vaccin*+inactivated+“formalin-killed”+“formaldehyde-killed”+dental+formalinized)+@NOT+@org+pubmed+pubdart+“NIH+reporter”
Toxline; searched 9/3/2014 | @SYN0+@AND+(@OR+“Adaptive+immunity”+asthma+“atopic+dermatitis”+immune+“innate+im munity”+redox+allergic+allergy+“mucosal+immunity”+Eosinophil*+Inflammation+“Lung+function +test”+“Nitric+oxide”+Wheezing+rhinosinusitis+lymphocyte+bronchiolitis+glucocorticoid+IgE+bas ophil+“histamine-releasing+factor”+“mast+cell”+“reactive+nitrogen+species”+“oxidative+stress”+isoprostane+“Air way+remodeling”+phagocytosis+“toll-like”+“respiratory+immunity”+autoimmune+interleukin+“immune+system”+“allergic+rhinitis”+“c hronic+obstructive+pulmonary+disease”)+(@OR+formaldehyde+formalin+@term+@rn+50-00-0)+@NOT+(@OR+nocicept*+pain+“formalin+test”+“formalin-induced”+“formaldehyde-fixed”+“formalin-fixed”+“paraformaldehyde-fixed”+“formaldehyde+fixation”+“formalin+fixation”+“buffered+formalin”+“neutral+buffered+for malin”+vaccin*+inactivated+“formalin-killed”+“formaldehyde-killed”+dental+formalinized)+@AND+@org+“nih+reporter”
Toxline; searched 9/3/2014 | Part 2; @SYN0+@AND+(@OR+copd+corticosteroids+“Chronic+bronchitis”+fibrocyte+hematopoie*+“Epit helial+injury”+“epithelial+repair”+Th17+“Airway+hyperresponsiveness”+“Airway+smooth+muscle “+“airway+hyperreactivity”+“Bronchoalveolar+lavage”+neutrophil+cytokine+Bronchiectasis+th2+t h9+“t+cell”+leukotriene+“Bronchial+epithelial+cell”+“Dendritic+cell”+Endothelin+“growth+factor “+Lipoxins+Prostaglandin+cyclooxygenase+“matrix+metalloproteinase”+ovalbumin+“tumor+necr osis+factor”+Phosphodiesterase+“Bronchopulmonary+dysplasia”+Adipokine+Eicosanoid+broncho constriction+Phospholipase+Hyperpnoea+bronchiectasis+“corticosteroid+responsiveness”+“Type +2”+“muscarinic+receptor+antagonism”+“obstructive+airway”+Immunomodulation+lipocalins+all ergen+corticosteroids+“Vascular+endothelial+growth+factor”+bronchiectasis+immunodeficiency +“Muscarinic+receptor”+inflammatory+Complement+“Myeloid+suppressor+cell”+immunoglobuli n+mucin+Autophagy+Leukocyte+macrophage+BALT+“extracellular+lining+fluid”)+(@OR+formald ehyde+formalin+@term+@rn+50-00-0)+@NOT+(@OR+nocicept*+pain+“formalin+test”+“formalin-induced”+“formaldehyde-fixed”+“formalin-fixed”+“paraformaldehyde-fixed”+“formaldehyde+fixation”+“formalin+fixation”+“buffered+formalin”+“neutral+buffered+for malin”+vaccin*+inactivated+“formalin-killed”+“formaldehyde-killed”+dental+formalinized)+@NOT+@org+pubmed+pubdart+“NIH+reporter”
Toxline; searched 9/3/2014 | @SYN0+@AND+(@OR+copd+corticosteroids+“Chronic+bronchitis”+fibrocyte+hematopoie*+“Epit helial+injury”+“epithelial+repair”+Th17+“Airway+hyperresponsiveness”+“Airway+smooth+muscle “+“airway+hyperreactivity”+“Bronchoalveolar+lavage”+neutrophil+cytokine+Bronchiectasis+th2+t h9+“t+cell”+leukotriene+“Bronchial+epithelial+cell”+“Dendritic+cell”+Endothelin+“growth+factor “+Lipoxins+Prostaglandin+cyclooxygenase+“matrix+metalloproteinase”+ovalbumin+“tumor+necr osis+factor”+Phosphodiesterase+“Bronchopulmonary+dysplasia”+Adipokine+Eicosanoid+broncho constriction+Phospholipase+Hyperpnoea+bronchiectasis+“corticosteroid+responsiveness”+“Type +2”+“muscarinic+receptor+antagonism”+“obstructive+airway”+Immunomodulation+lipocalins+all ergen+corticosteroids+“Vascular+endothelial+growth+factor”+bronchiectasis+immunodeficiency +“Muscarinic+receptor”+inflammatory+Complement+“Myeloid+suppressor+cell”+immunoglobuli n+mucin+Autophagy+Leukocyte+macrophage+BALT+“extracellular+lining+fluid”)+(@OR+formald ehyde+formalin+@term+@rn+50-00-0)+@NOT+(@OR+nocicept*+pain+“formalin+test”+“formalin-induced”+“formaldehyde-fixed”+“formalin-fixed”+“paraformaldehyde-fixed”+“formaldehyde+fixation”+“formalin+fixation”+“buffered+formalin”+“neutral+buffered+for malin”+vaccin*+inactivated+“formalin-killed”+“formaldehyde-killed”+dental+formalinized)+@AND+@org+“nih+reporter”

Abbreviations: Majr = major topic (filter); TS = the requested “topic” is included as a field tag.

#### Literature Search Results through 2016

Figure B-11 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and mechanistic data associated with potential noncancer effects on the respiratory system

#### Literature Search Results from the Systematic Evidence Map Update through 2021

Figure B-12 Mechanistic inflammation and immune effects literature tree (interactive version here (https://hawc.epa.gov/summary/visual/assessment/100500053/Mechanistic_inflammation/))

A total of 1,411 citations were retrieved for the assessment of mechanistic information on inflammation and immune responses (in the respiratory system or at systemic sites) and 56 studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

Of the 56 studies that met the PECO criteria (see Table B-12), eight were deemed to be possibly impactful (note: one possibly impactful study is repeated under both the animal and in vitro/ex vivo sections). (Sapmaz et al., 2015; Murta et al., 2016; Morgan et al., 2017; Lima et al., 2015; da Silva et al., 2015; Aydin et al., 2014; Abreu et al., 2016) and (Bellisario et al., 2016) were identified in the literature search update and included in the inventory table although they had been included in the 2017 draft Toxicological Review of Formaldehyde (Inhalation). In vitro/ex vivo study designs and a study of endogenous formaldehyde biology also were included.

Table B-12 Mechanistic studies relating to respiratory or systemic inflammatory and immune responses

Reference | Study design | Exposure^a^ | Mechanistic endpoints | Impactful? | Rationale
Human Studies
Bassig et al. (2016) | Occupational Guangdong, China Cross-sectional | Air sampling Adult formaldehyde factory workers | WBC counts in blood, with subtype analyses of cells of both myeloid and lymphoid lineage (include CD4 T cell subtyping and cell activation markers) | Possibly impactful | PBL sub-population analyses and lineage are key endpoints of concern
Costa et al. (2019) | Occupational Portugal Cross-sectional | Air sampling Adult anatomy-pathology laboratory workers | Lymphocyte counts, subpopulations analyses | Possibly impactful | PBL sub-population analyses and lineage are key endpoints of concern
Augenreich et al. (2020) | Occupational Boone, North Carolina, USA Cohort | Air sampling Adult medical students in anatomy dissection rooms | Circulating markers of oxidative stress and inflammation; brachial artery dilation (arm), reactive hyperemia (leg), blood pressure/pulse/heart rate | Not impactful | ROS measures not key endpoints of concern
Bellisario et al. (2016) | Occupational Torino, Italy cross-sectional | Air sampling, adults, Female surgical nurses | Biomarkers of oxidative stress (urinary malondialdehyde and 15-F2t-isoprostane) | Not impactful | Already included in 2017 draft; ROS measures not key endpoints of concern
Bruno et al. (2018) | Occupational Rome, Italy Cross-sectional | Air sampling Adult pathology laboratory workers | Counts of neutrophils, eosinophils, lymphocytes, macrophages, ratio of mucous-secreting cells and ciliated cells in the middle portion of the inferior turbinate | Not impactful | Cell counts (without sub-analyses) not key endpoints of concern
Ghelli et al. (2020) | Occupational Turin, Italy Cohort | Air sampling Adult (female) hospital workers | ROS measures in urine and inflammatory markers and cytokines in blood. Genotyped for CYP1A1, GSTT1, GSTM1, TNFa, and IL-6 polymorphisms | Not impactful | ROS and cytokine-related measures not key endpoints of concern
Isa et al. (2020a) | School-based Selangor, Malaysia Cross-sectional | Air sampling School children | Fractional exhaled nitric oxide (FeNO, an airway ROS/inflammation marker) | Not impactful | ROS markers not key endpoints of concern
Isa et al. (2020b) | School-based Hulu Langat, Selangor, Malaysia Cross-sectional | Air sampling, children, Suburban and urban school children | Inflammatory cytokine markers in sputum; exhaled FeNO | Not impactful | ROS and cytokine-related measures not key endpoints of concern
Yon et al. (2019) | School-based Seongnam City, Korea Cohort | Air sampling School children | Serum formaldehyde-specific IgE; airway function; and exhaled FeNO | Not impactful | ROS and antibody-related measures not key endpoints of concern
Animal Studies
Liu et al. (2017) | Mouse (ICR), male Subchronic (20 wk; 2 hr/d) | Unspecified test article 0, 1, 10 mg/m^3^ Inhalation | Bone marrow cell MN; polychromatic erythrocytes (PCE)/normochromatic erythrocyte (NCE) ratio (immature/mature RBCs) | Possibly Impactful | Key endpoints of concern; longer duration study is rare (note: presumed use of formalin limits interpretation)
Ma et al. (2020) | Mouse (Balb/c), male Subchronic (8 wk; 8 hr/d, 7 d/wk) | Formaldehyde in water (methanol free) 0, 2 mg/m^3^ Inhalation | DNA damage (comet assay) in peripheral tissues (e.g., spleen; thymus); % of CD4+ T cells, CD8+ T cells, ratio of CD4+/CD8+ cells, and CD4 and CD8 cell phenotyping spleen weights, percentage of the DN (double negative), DP (double positive), CD4SP (single positive) and CD8SP cell populations in the isolated thymocytes, cytotoxicity in CD4SP and CD8SP cells, Runx (Runx 1,2,3, C), Runx1, Runx3, and ThPOK expression in the DP cells, ROS | Possibly impactful | Key endpoints of concern regarding immune cell health and function
Morgan et al. (2017) | Mouse (Trp53 haploinsufficient), Male Subchronic (8 wk; 6 hr/d, 5 d/wk), then held for 32 wk | Paraformaldehyde 0, 7.5 or 15 ppm (0, 9.23, 18.5 mg/m^3^) Inhalation | Hematology | Possibly impactful | Already included in 2017 draft
Park et al. (2020) | Mouse (BALB/c), female Short-term (2 wk; 4 hr/d, 5 d/wk) | Fresh formaldehyde solution (methanol-free) 0, 1.38, 5.36 mg/m^3^ Inhalation | Splenic cytokines, T cell populations and Th1/Th2 balance, differentiation markers | Possibly impactful | T cell subpopulation analyses are key endpoints of concern
Zhao et al. (2020) | Mouse (Balb/c), male Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin 0, 3 mg/m^3^ Inhalation | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies in nose, lung, spleen, and bone marrow | Possibly impactful (POE tissues); Not impactful (systemic tissues) | Key endpoints of concern (note: formalin; in vitro are of less concern for POE tissues)
Aydemir et al. (2017) | Rat (Wistar albino), both sexes Subchronic (6 wk; 8 hr/d, 5 d/wk) | Formalin 0, 6 ppm (0, 7.4 mg/m^3^) Inhalation (note: i.p. not PECO relevant) | Blood DNA damage (comet assay) and ROS markers | Not impactful | Formalin; high level
Aydin et al. (2014) | Rat (Sprague-Dawley), male Short-term (4 wk) | Formalin 0, 5.27, 10.02 ppm (0, 6.48, 12.3 mg/m^3^) Inhalation | Serum and lung total antioxidant and oxidant status, and oxidative stress index; serum glucose, protein, albumin, lipids, cholesterol, HDL, LDL, triglyceride, T protein; lung irisin levels and immunostaining | Not impactful | Already included in 2017 draft; Note: ROS and serum
Bernardini et al. (2020) | Mouse (Swiss), male Short-term (4 wk; 4 hr/d, 5 d/wk) | Unspecified test article 0, 0.5, 1, 5, 10 ppm (0, 0.62, 1.23, 6.15, 12.3 mg/m^3^) Inhalation | Lung histopathology; BAL cell counts and inflammatory and ROS markers; global methylation in blood and bone marrow | Not impactful | Unknown test article; not key endpoints of concern
Cheng et al. (2016) | Mouse (Kunming), male Short-term (3 or 7 d; continuous) | Formalin 0, 0.08, 0.8 mg/m^3^ Inhalation | Serum CD4+, CD8+, and CD4/CD8 T cell counts | Not impactful | Formalin
Abreu et al. (2016) | Mouse (C57BL/6), female Acute (single exposure, assessed 8 hr later) | Unspecified test article 0, 0.2, 1, 3 ppm (0, 0.25, 1.23, 3.69 mg/m^3^) Inhalation | Lung mechanics and morphology, inflammatory cell counts and cytokines, and ROS markers | Not impactful | Already included in 2017 draft; Note: unknown test article; acute
da Silva et al. (2015) | Rat (Wistar), male Short-term (3 d; 90-min/d) | Unspecified test article 0, 1 % Inhalation | BAL cell counts (WBCs, Mono., Lympho., Neutro., Eosin.), cytokines, and myeloperoxidase activity (inflammation); lung morphometrics, microvascular permeability, and mRNA levels | Not impactful | Already included in 2017 draft; Note: unknown test article; high levels
Duan et al. (2018) | Mouse (BALB/c), male Short-term (18 d; 5 hr/d) | Formalin 0, 1 mg/m^3^ Inhalation | Pulmonary eosinophil cationic protein (histopathology), ROS markers, nuclear factor kappa B activation, and cytokine and growth factor levels | Not impactful | Formalin; no saline plus formaldehyde control group
Duan et al. (2020) | Mouse (Balb/c), male Short-term (21 d; 6 hr/d) | Formalin 0, 0.5 mg/m^3^ Inhalation | Airway IgE, cytokines and inflammatory factors, Th1/Th2 balance, mucus secretion, histopathology, and lung function | Not impactful | Formalin; not key endpoints of concern
Ge et al. (2020a) | Mouse (Balb/c), male Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin 0, 0.5, 3 mg/m^3^ Inhalation | CBC; Myeloid progenitor cell (BFU-E and CFU-GM) colony counts and cytokines; circulating ROS and cytokine markers; bone marrow histology, ROS, and gene expression of cell cycle and DNA damage markers | Not impactful | Formalin
Han et al. (2016) | Rat (Sprague-Dawley), male Subchronic (6 wk; 2 hr/d, 5 d/wk beginning at PND3 | Paraformaldehyde 0, 0.83, 1.16 ppm (0, 1.02, 1.43 mg/m^3^) Inhalation | Serum IgE, thymus Th1 and Th2 cytokines, body weight | Not impactful | Nonspecific antibodies and cytokines not key endpoints of concern
Jin et al. (2021) | Mouse (C57BL/6J), both sexes Short-term (4 d; 6 hr/d) | Unspecified test article 0, 5 ppm (0, 6.15 mg/m^3^) Inhalation | Respiratory parameters (e.g., rate) during exposure; serum lipids; serum cell counts and soluble factors (CBC) | Not impactful | Unknown test article; not key endpoints of concern
Kang et al. (2018) | Mouse (BALB/c), male Short-term (18 d; 5 hr/d) | Formalin 0, 1 mg/m^3^ Inhalation | Serum IgE, IgG; airway hyperreactivity, ROS markers, nuclear factor kappa B and MAPK activation; cytokine levels, and mast cell degranulation | Not impactful | Formalin; not key endpoints of concern
Leal et al. (2018) | Mouse (C57BL6), male Short-term (2 wk; 1 hr/d, 5 d/wk) | Unspecified test article 0, 0.92 mg/m^3^ Inhalation | Lung cytokines and elasticity measures | Not impactful | Unknown test article; not key endpoints of concern
Li et al. (2017) | Mouse (Balb/c or C57BL/6), male Short-term (25 d; 6 hr/d) | Formalin 0, 0.5, 3 mg/m^3^ Inhalation | Bronchial responsiveness (to methacholine), BAL cytokines and cell counts (total, eosin., lympho., neutro.); Serum OVA-specific IgE, IgG1, and IgG2a | Not impactful | Formalin; not key endpoints of concern
Lima et al. (2015) | Rat (Fischer), male Short-term (5 d; 20-min x3/d) | Unspecified test article 0, 1, 5, 10 % Inhalation | Trachea histology and morphometric analyses, including mucus production, glycogen, ROS markers, and inflammatory cell counts. | Not impactful | Already included in 2017 draft; Note: Unknown test article; high levels
Liu et al. (2018b) | Rat (Sprague Dawley), male Short-term (4 wk; 8 hr/d) | Formalin 0, 0.5, 5, 10 mg/m^3^ Inhalation | Lung autophagy, histopathology and BAL cytokines | Not impactful | Formalin; not key endpoints of concern
Macedo et al. (2016b) | Rat (Wistar), male Short-term (3 d; 90-min/d) | Formalin 0, 1 % Inhalation | BAL ROS markers and cellular oxidative burst; lung tissue antioxidant enzyme measures | Not impactful | Formalin; high levels
Murta et al. (2016) | Rat (Fischer), male Short-term (5 d; 20-min × 3/d) | unspecified 0, 1, 5, 10 %, inhalation | BALF cell counts (WBCs, macrophages, lymphocytes, neutrophils, eosinophils), inflammatory and ROS markers, and neutrophil ROS production Lung tissue inflammatory markers, H&E staining and morphometry | Not impactful | Already included in 2017 draft; Note: unknown test article; high levels
Payani et al. (2019) | Rat (Wistar, albino), male Short-term (21 d; 1 hr/d) | Unspecified test article 0, 40 % Inhalation | Lung ROS markers | Not impactful | Unknown test article; high levels
Sapmaz et al. (2015) | Rat (Sprague-Dawley), male Short-term (4 wk; 8 hr/d) | Paraformaldehyde 0, 5, 10 ppm (0, 6.15, 12.3 mg/m^3^) Inhalation | Serum total IgA, IgM, IgG, complement C3 | Not impactful | Already included in 2017 draft; Note: Nonspecific antibody-related measures not key endpoints of concern
Sholapuri et al. (2020) | Rat (Wistar), male Short-term (21 d; 1 hr/d) | Formalin 0, 40 % Inhalation | Hematology parameters (CBC); BAL histamine; lung histology | Not impactful | Formalin; high levels
Song et al. (2017) | Mouse (Balb/c), male Short-term (25 d) | Formalin 0, 2.44 ppm (0, 3 mg/m^3^) Inhalation | Serum levels of cytokines, neuropeptides, ROS, and IgE; leukocyte counts and cellular antioxidant levels. | Not impactful | Formalin; No formaldehyde-only control (without OVA);
Wei et al. (2017b) | Mouse (BALB/c), male Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin 0, 3 mg/m^3^ Inhalation | Complete blood cell count; bone marrow - myeloid progenitor formation assay, ROS assay, IL-3 and GM-CSF ELISA, systemic toxicity, bone marrow cellularity, apoptosis assay | Not impactful | Formalin; short-term (otherwise impactful endpoints)
Wei et al. (2017a) | Mouse (BALB/c), male Short-term (2 wk; 5 d/wk), followed by 7 d recovery | Formalin 0, 3 mg/m^3^ Inhalation | Complete blood cell count, bone marrow histopathology, myeloid progenitor colonyforming cell assay, ROS and cytokine measures, and DNA-protein crosslinks | Not impactful | Formalin; short-term (otherwise impactful endpoints)
Wen et al. (2016) | Mouse (Balb/c), male Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin 0, 3 mg/m^3^ Inhalation | Cell counts (WBCs, lymphocytes, monocytes, neutrophils, RBCs, platelets); serum antibody (total) level; ROS markers; PBL proliferation; serum hemagglutination titer and delayed-type hypersensitivity (both after sheep RBC injection) | Not impactful | Formalin (limits interpretability of systemic effects)
Wu et al. (2020) | Mouse (Balb/C), male Short-term (21 d; 5 hr/d) | Formalin 0, 0.8 mg/m^3^ Inhalation | Pulmonary function; lung histopathology; airway hyperresponsiveness; lung IgE and cytokine (including Th1/Th2) levels | Not impactful | Formalin; not key endpoints of concern
Zhang et al. (2018b) | Mouse (Balb/c), male Short-term (7, 14, or 28 d, 2 4hr/d for constant and 12 hr/d for intermittent) | Unspecified test article 0, 0.8 (intermittent) or 0, 0.4 (constant) ppm (0, 0.49, or 0.98 mg/m^3^) Inhalation | BAL cell counts (total, eosin., neutro., lympho.); lung tissue ROS markers, histology, and cytokine and inflammatory marker immunohistochemistry | Not impactful | Unknown test article; not key endpoints of concern
In Vitro/Ex Vivo Studies
Zhao et al. (2020) | Mouse (Balb/c), male Ex vivo primary lung and nose cells (systemic cells not PECO-relevant) Acute (1 hr) | Formalin 0, 50, 100, 200, 400 μM In media | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies | Possibly impactful | Key endpoints of concern (note: formalin; in vitro are of less concern for POE tissues)
An et al. (2019) | Human immortalized bronchial epithelial cells (in vitro experiments in LHP-relevant cells were excluded) Acute (2 hr) | Unspecified test article 0, 20, 40, 60, 80, 100, 120 μM In media | Cell proliferation, ROS production, and markers of cell division/proliferation and ROS | Not impactful | Unknown test article; in vitro; acute
Arslan-Acaroz and Bayşu-Sozbilir (2020) | Human immortalized lung epithelial cells Acute (4 hr) | Unspecified test article 0, 100 μM, In media | Cell viability and ROS markers | Not impactful | Unknown test article; in vitro; acute
Boncler et al. (2019) | Human immortalized lung epithelial cells (other in vitro experiments in this study excluded as not PECO relevant) Acute (24 hr) | Unspecified test article 0, 63, 126, 378, 504, 630 μmol/L In media | Cell viability and mitochondrial membrane potential | Not impactful | Unknown test article; in vitro; acute
Cui et al. (2016) | Human immortalized lung cells or Mouse (Balb/c) nasal instillation Acute up to 48 hr | Unspecified test article 0, 200 μM In media or instilled | Cell signaling and gene expression, ROS, and cellular currents | Not impactful | Unknown test article; acute
Gostner et al. (2016) | Human immortalized, lung epithelial cells Short-term (3 d) | Unspecified test article 0, 0.1, 0.5 ppm (0, 0.12, 0.62 mg/m^3^) Gaseous exposure at the air:liquid interface | Cell viability; gene expression | Not impactful | Unknown test article; not key endpoints of concern
Jude et al. (2016) | Human primary airway smooth muscle (HASM) cells Acute (1 hr, assessed at 24 hr) | Formalin0, 0.2, 0.8, 2 ppm (0, 0.25, 0.98, 2.46 mg/m^3^) Vapor delivered to cells | Agonist-induced calcium mobilization, cytotoxicity, ROS markers and cytokines in co-cultures; cabachol-induced airway narrowing in slices | Not impactful | Formalin; in vitro; acute
Kim et al. (2018) | Human immortalized endometrial adeno-carcinoma cells Short-term (6 d) [Note: study included due to use of this cell line to examine mechanisms associated with epithelial cell-cell interactions] | Unspecified test article 10-11 to 10-3 M In media | ROS production, protein expression of markers associated with cell transformation and proliferation | Not impactful | Unknown test article; in vitro
Li et al. (2008) | Human immortalized tracheal epithelial cells Acute (4 or 24 hr) | Unspecified test article 0, 20, 50, 100, 200 μM In media | Cell viability and expression of MAPK-responsive genes | Not impactful | Unknown test article; in vitro; acute
Liu et al. (2019) | Human immortalized bronchial epithelial cells Acute (24 hr) | Unspecified test article 0, 40, 80, 160 μmol/L In media | Apoptosis, PI3K-Akt pathway signaling markers | Not impactful | Unknown test article; in vitro; acute
Mi et al. (2019) | Human pulmonary alveolar epithelial cells in artificial airway Acute (2, 4, or 6 hr) | Unspecified test article 0.025 and 40 μM (0.025 μM = ~0.3 ppm) Nitrogen carrier-mediated delivery directly into cells | ROS and cytokine markers | Not impactful | Unknown test article; acute
Nazarparvar-Noshadi et al. (2020) | Human immortalized lung epithelial cells Acute/short-term (24, 48, and 72 hr) | Unspecified test article 0, 25, 50, 100, 150, 200, 300 μM In media | Cellular viability and DNA damage markers | Not impactful | Unknown test article; in vitro
Vitoux et al. (2018) | Human immortalized conjunctival epithelial cells Acute (15–30 min, assess at 1 or 24 hr) | Formalin 0, 100, 1,200 μg/m^3^ Airflow over cells | Expression of inflammatory cytokines | Not impactful | Formalin; in vitro; acute
Zhang et al. (2019) | Human immortalized lung bronchial cells Acute (3, 6, 12, or 24 hr) | Formalin 0, 5, 10, 20, 40, 80 μmol/L In media | ROS and cytotoxicity markers m | Not impactful | Formalin; in vitro; acute
Zhang et al. (2020b) | Human Immortalized bronchial epithelial cells | Formalin 0, 10, 40, 80 μM 24 hr | DNA damage - comet assay; apoptosis; mitochondria-mediated apoptosis; reactive oxygen species levels | Not impactful | Formalin; in vitro; endpoints well-established in vitro
Models, Endogenous Formaldehyde, or Other Studies
Dingler et al. (2020) | Mouse (C57BL/6 background), ALDH2 and ALDH5 WT, single, and double KO, both sexes (note: also includes primary cultures of human PBLs, fibroblasts, and buccal cells not deemed PECO-relevant) | No formaldehyde inhalation exposures (note: included since it evaluates essentiality of formaldehyde detoxification processes in normal function) | Genotoxicity in peripheral blood cells and bone marrow (MN assay, SCE); bone marrow stem cell and progenitor cell quantification, lineage characterization, and B cell maturation; thymic development and cell lineage characterization; complete blood cell count, cell cycle profiling | Possibly impactful | No formaldehyde inhalation but included as a reference study for discussion of potential sources of susceptibility relating to formaldehyde detoxification; cell production from bone marrow is a key endpoint of concern

Abbreviations: WBC = white blood cell; ROS = reactive oxygen species; BAL = bronchoalveolar lavage (F = fluid); RBC = red blood cell; PBL = peripheral blood leukocyte; CBC = complete blood cell (count).

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

a Use of methanol-stabilized formalin was inferred in some studies based on study-specific description (e.g., 37% stock solution).

### B.2.7 Nervous System Effects

As detailed in Section 2.2.7 of the Toxicological Review, the review of nervous system effects focused on studies in humans or animals that examined objective, apical effects on the nervous system, including structural, behavioral, chemical, and electrophysiological changes, as well as mechanistic studies. A single search strategy (with different PECO screening criteria) was used to capture studies in humans and animals, as well as relevant in vivo mechanistic studies. As described in Section 2 of the Toxicological Review, studies of symptoms were not included. The search strings are documented in Table B-13, the literature search results through 2016 are documented in Figure B-13, and the literature search results through 2021 identified by the SEM are documented in Figure B-14, with the SEM screening decisions documented in the subsequent section.

#### Search Strings

Table B-13 Summary of search terms for nervous system effects

Database, Search Parameters | Terms
PubMed; No date restriction | (formaldehyde [majr] OR paraformaldehyde) AND (neuron OR neurons OR neurono* OR neurolo* OR neuronal OR neurotox* OR neurophys* OR neurochem* OR neurotrans* OR neuropsych* OR neuropath* OR neuromusc* OR nerve OR nerves OR nervous OR electrophys* OR “evoked potential” OR *encephalog* OR encephalop* OR *sensory OR sensori* OR “central nervous system” OR CNS OR brain OR spine OR spinal OR spino* OR *axon* OR *synapt* OR *synaps* OR *myelin* OR dendrite* OR *behavior* OR learn* OR memory OR *motor OR *motion OR operant OR habituat* OR *coordination OR weakness OR righting OR reflex OR psychologic* OR mood OR sleep* OR visual OR audit* OR touch OR taste OR sound OR smell OR “pain sensitivity” OR nociception OR olfact* OR *glia* OR oligoden* OR astrocyte* OR balance OR sensation OR sensitization OR tremor* OR convuls* OR seizure* OR grip OR gait OR paralysis OR posture OR mobility OR rearing OR splay OR stereotypy OR conditioning OR avoidance OR approach OR neuropath* OR attenti* OR aggressi* OR arous*)
PubMed; No date restriction | NOT (“formalin test” OR “formaldehyde fixation” OR “formalin fixation” OR “formalin fixed” OR “formaldehyde fixed” OR “formalin-induced” OR “formalin-evoked”) [Note: for quality control, ≈10% (50) of the 451 excluded article titles were scanned in PubMed: none were relevant]
Web of Science; No date restriction Lemmatization “off” | SU= (“Anatomy & Morphology” OR “Behavioral Sciences” OR “Biochemistry & Molecular Biology” OR “Cell Biology” OR “Developmental Biology” OR “Life Sciences Biomedicine Other Topics” OR “Neurosciences & Neurology” OR Pathology OR Pediatrics OR Physiology OR “Public, Environmental & Occupational Health” OR “Reproductive Biology” OR “Research & Experimental Medicine” OR Toxicology OR “Veterinary Sciences” OR Psychology) AND TS= (formaldehyde OR paraformaldehyde OR formalin) AND TS= (neuron OR neurons OR neurono* OR neurolo* OR neuronal OR neurotox* OR neurophys* OR neurochem* OR neurotrans* OR neuropsych* OR neuropath* OR neuromusc* OR nerve OR nerves OR nervous OR electrophys* OR “evoked potential” OR *encephalog* OR encephalop* OR *sensory OR sensori* OR “central nervous system” OR CNS OR brain OR spine OR spinal OR spino* OR *axon* OR *synapt* OR *synaps* OR *myelin* OR dendrite* OR *behavior* OR learn* OR memory OR *motor OR *motion OR operant OR habituat* OR *coordination OR weakness OR righting OR reflex OR psychologic* OR mood OR sleep* OR visual OR audit* OR touch OR taste OR sound OR smell OR “pain sensitivity” OR nociception OR olfact* OR *glia* OR oligoden* OR astrocyte* OR balance OR sensation OR sensitization OR tremor* OR convuls* OR seizure* OR grip OR gait OR paralysis OR posture OR mobility OR rearing OR splay OR stereotypy OR conditioning OR avoidance OR approach OR neuropath* OR attenti* OR aggressi* OR arous*)
| NOT TS= (“formalin test” OR “formaldehyde fixation” OR “formalin fixation” OR “formalin fixed” OR “formaldehyde fixed” OR “formalin-induced” OR “formalin-evoked”) [Note: for quality control, ≈2% (80) of the 3,825 excluded article titles were scanned in WoS: none were relevant].
ToxNet (Toxline and DART); No date restriction | formaldehyde AND (neurol* OR neurotox*); (including synonyms and CAS numbers, but excluding PubMed records)
TCATS2; Restricted to 01/01/2010 and newer | “formaldehyde” OR CAS Number: “50-00-0”

#### Literature Search Results through 2016

Figure B-13 Literature search documentation for sources of primary data pertaining to formaldehyde exposure and nervous system effects

#### Literature Search Results from the Systematic Evidence Map Update through 2021

Figure B-14 Nervous system effects literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Nervous-system/))

A total of 2,617 citations were retrieved for the assessment of nervous system effects and 14 studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

Of the 14 studies that met PECO criteria, two human studies were deemed to be possibly impactful (see Table B-14). Peters et al. (2017) was identified in the literature search update and deemed to be possibly impactful, but already had been included in the 2017 draft. None of the identified animal or mechanistic studies were deemed possibly impactful. Thus, zero (0) additional studies were included.

Table B-14 Studies of nervous system effects

Reference | Study design | Exposure^a^ | Endpoints | Impactful? | Rationale
Human Studies
Bellavia et al. (2021) ^b^ | General population Denmark case-control | Occupational history and job-exposure matrix, adults | Amyotrophic lateral sclerosis (ALS) incidence | Possibly impactful | Key endpoint of concern
Peters et al. (2017) | General population Sweden case-control | Occupational history and job-exposure matrix, adults | Amyotrophic lateral sclerosis (ALS) incidence | Possibly impactful | Already identified in 2017 draft
Animal Studies^c^
Askar and Halloull (2018) | Rat (Albino, strain not specified), male. Subchronic (12 wk; 6 hr/d, 5 d/wk) | Paraformaldehyde 0, 20 ppm (0, 24.6 mg/m^3^) Inhalation | Cerebellar histopathology, cell counts, and cell morphology; evaluations of ROS and inflammatory markers | Not impactful | High levels
Cheng et al. (2016) | Mouse (Kunming), male Short-term (Up to 7 d; continuous) | Formalin 0, 0.08, 0.8 mg/m^3^ Inhalation | Morris water maze | Not impactful | Formalin
Duan et al. (2018) | Mouse (Balb/c), male Short-term (18 d; 5 hr/d) | Formalin 0, 1 mg/m^3^ Inhalation | Prefrontal cortex histology; brain ROS and inflammation markers, cytokines | Not impactful | Formalin; no saline plus formaldehyde control group
Ge et al. (2019) | Mouse (Kunming), male Short-term (21 d; continuous) | Formalin 0, 1 mg/m^3^ Inhalation | Morris water maze, hippocampal morphology, brain ROS and cell signaling markers | Not impactful | Formalin
Huang et al. (2019) | Mouse (Kunming), male Short-term (14 d; 8 hr/d) | Formalin 0, 3 mg/m^3^ Inhalation | Morris water maze; brain ROS and inflammatory markers; hippocampal histopathology and cell morphology | Not impactful | Formalin
Li et al. (2016) | Mouse (Kunming), male Short-term (7 d; 2 hr/d) | Formalin 0, 1, 2 ppm (0, 1.23, 2.46 mg/m^3^) Inhalation | Open field activity; elevated plus maze test; forced swimming test; novel object recognition; counts of TH- and GR-immunoreactive neurons | Not impactful | Formalin; brief exposures
Li et al. (2020) | Mouse (Kunming), male Short-term (14 d; 8 hr/d) | Formalin 0, 0.5, 3 mg/m^3^ Inhalation | Morris water maze; brain ROS and inflammatory markers; hippocampal histopathology and cell morphology | Not impactful | Formalin
| Mouse (Balb/c), male Short-term (7 d; 8 hr/d) | | Brain neurotransmitters; ROS and inflammatory markers in hippocampus, brain stem, and cerebral cortex
Mei et al. (2016) | Mouse (Balb/c), male Short-term (7 d; 8 hr/d) (in vitro experiments not PECO-relevant) | Unspecified test article 0, 3 mg/m^3^ Inhalation | Morris water maze; qualitative hippocampal neuron staining; brain ROS and GSH | Not impactful | Formalin
Zhang et al. (2014b) | Rat (Sprague Dawley), male Short-term (14 d; 30-min, 2×/d) | Unspecified test article 0, 13.5 ppm (0, 16.6 mg/m^3^) Inhalation | Buried food pellet behavioral testing; olfactory bulb synaptosomal and neuronal markers; olfactory sensory neuron maturation | Not impactful | Unknown test article; high levels; brief exposures
Mechanistic Studies
Cao et al. (2015) | Mouse (Balb/c), male Short-term (7 d; 8 hr/d) | Unspecified test article 0, 0.5, 3 mg/m^3^ Inhalation | Hippocampus, cortex, and brainstem ROS and inflammatory markers | Not impactful | Unknown test article
Eom et al. (2017) | Drosophila melanogaster (mutant strains: WT, p53 and p38b) Acute (6 or 24 hr) | Unspecified test article 0, 10, 100 μg/m^3^ Inhalation | Behavioral (movement-based) quantification; microarray analyses (note survival test study design not extracted) | Not impactful | Non-mammalian; unknown test article
Li et al. (2015) | mouse (ICR), male, Acute or short-term (1 or 7 d; 6 hr/d) | Unspecified test article 0, 3 ppm (0, 3.69 mg/m^3^) Inhalation | miRNA screening of olfactory bulb | Not impactful | Unknown test article

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

a Use of methanol-stabilized formalin was inferred in some studies based on study-specific description (e.g., 37% stock solution).

b An additional study, (Seals et al., 2017), was identified from the reference list of (Bellavia et al., 2021). As this study was determined to be possibly impactful, it was incorporated into the Toxicological Review.

c Animal studies may include evaluation of mechanistic endpoints.

### B.2.8 Developmental and Reproductive Effects

As detailed in Section 2.2.8 of the Toxicological Review, the review of developmental and reproductive effects included separate searches for human and animal studies, including in vivo studies of mechanistic endpoints. The human searches focused on time-to-pregnancy (TTP) as a measure of fecundability, reproductive parameters in males (e.g., semen parameters), spontaneous abortion, and birth outcomes (e.g., birthweight, malformations). Outcomes assessed in animal toxicology studies included developmental toxicity (prenatal survival, fetal and postnatal growth, and structural alterations and malformations), male reproductive toxicity (sperm count and morphology, testes and epididymal weight and histopathology, and functional measures), and female reproductive toxicity (hormone levels, ovarian and uterine weight and histopathology, and early embryo loss). Functional developmental outcomes (i.e., developmental neurotoxicity) were addressed in the section on potential nervous system effects (see also Appendix B.2.7). The search strings are documented in Table B-15, the literature search results through 2016 are documented in Figure B-15, and the literature search results through 2021 identified by the SEM are documented in Figure B-16, with the SEM screening decisions documented in the subsequent section.

#### Search Strings

Table B-15 Summary of search terms for developmental or reproductive toxicity

Database, search date | Terms
PubMed; No date restriction | (formaldehyde [majr] OR paraformaldehyde OR formalin) AND (“reproductive toxicity” OR “reproductive toxicology” OR reproductive OR “developmental toxicity” OR “developmental toxicology” OR development OR developmental OR ontogen* OR “embryo toxicity” OR embryo OR embryon* OR embryog* OR embryot* OR “fetal loss” OR fetal OR fetus OR fetuses OR fetotoxi* OR miscarriage or miscarry OR “spontaneous abortion” OR “preimplantation loss” OR preimplantation OR “postimplantation loss” OR postimplantation OR implantation OR conception OR resorption OR fertility OR fertile OR infertility OR infertile OR pregnancy OR gestation OR neonatal OR neonate OR prenatal OR postnatal OR “menstrual cycle” OR “premature birth” OR “preterm birth” OR “low birth weight” OR “in utero” OR “fetal body weight” OR “fetal weight” OR pup OR “pup body weight” OR “pup weight” OR ovary OR ovaries OR ovu* OR sperm OR gamete OR “germ cells” OR “Sertoli cells” OR testes OR testis OR testic* OR uterus OR uteri* OR epididy* OR prostate OR “seminal vesicles” OR semen OR testosterone OR “luteinizing hormone” OR LH OR “follicle stimulating hormone” OR FSH OR estrogen OR estradiol OR “time to pregnancy” OR “time-to-pregnancy” OR TTP OR fecund*)
PubMed; No date restriction | NOT (fixative OR “formaldehyde fixation” OR “paraformaldehyde fixation” OR “formalin fixation” OR “formaldehyde fixed” or “paraformaldehyde fixed” OR “formalin fixed” OR “formaldehyde-fixed” or “paraformaldehyde-fixed” OR “formalin-fixed” OR formocresol OR dental OR dentistry OR immunogen OR vaccine OR vaccination OR metabolite) [Note: for quality control, ≈1% (75) of the 7,589 excluded article titles were scanned in PubMed: 2 potentially relevant government reports were found, and 4 duplicates were excluded, resulting in 2,810 in the final database.
Web of Science; No date restriction Lemmatization “off” | SU=(Toxicology OR “Pharmacology &Pharmacy” OR “Public, Environmental & Occupational Health” OR “Cell Biology” OR “Reproductive Biology” OR “Biochemistry & Molecular Biology” OR Pathology OR “Obstetrics & Gynecology” OR “Environmental Sciences” OR “Anatomy & Morphology” OR Andrology OR “Veterinary Sciences” OR Physiology OR “Developmental Biology” OR “Research & Experimental Medicine” OR “Life Sciences Biomedicine Other Topics” OR “Veterinary Sciences”) AND TS=(formaldehyde OR paraformaldehyde OR formalin) AND TS=(“reproductive toxicity” OR “reproductive toxicology” OR reproductive OR “developmental toxicity” OR “developmental toxicology” OR development OR developmental OR ontogen* OR “embryo toxicity” OR embryo OR embryon* OR embryog* OR embryot* OR “fetal loss” OR fetal OR fetus OR fetuses OR fetotoxi* OR miscarriage or miscarry OR “spontaneous abortion” OR “preimplantation loss” OR preimplantation OR “postimplantation loss” OR postimplantation OR implantation OR conception OR resorption OR fertility OR fertile OR infertility OR infertile OR pregnancy OR gestation OR neonatal OR neonate OR prenatal OR postnatal OR “menstrual cycle” OR “premature birth” OR “preterm birth” OR “low birth weight” OR “in utero” OR “fetal body weight” OR “fetal weight” OR pup OR “pup body weight” OR “pup weight” OR ovary OR ovaries OR ovu* OR sperm OR gamete OR “germ cells” OR “Sertoli cells” OR testes OR testis OR testic* OR uterus OR uteri* OR epididy* OR prostate OR “seminal vesicles” OR semen OR testosterone OR “luteinizing hormone” OR LH OR “follicle stimulating hormone” OR FSH OR estrogen OR estradiol OR “time to pregnancy” OR “time-to-pregnancy” OR TTP OR fecund*)
| NOT (fixative OR “formaldehyde fixation” OR “paraformaldehyde fixation” OR “formalin fixation” OR “formaldehyde fixed” or “paraformaldehyde fixed” OR “formalin fixed” OR “formaldehyde-fixed” or “paraformaldehyde-fixed” OR “formalin-fixed” OR formocresol OR dental OR dentistry OR immunogen OR vaccine OR vaccination OR metabolite)
ToxNet (Toxline and DART); No date restriction | (formaldehyde OR paraformaldehyde OR formalin) AND (“reproductive toxicity” OR “reproductive toxicology” OR reproductive OR “developmental toxicity” OR “developmental toxicology” OR developmental); (including synonyms and CAS numbers, but excluding PubMed records)

#### Literature Search Results through 2016

Figure B-15 Literature search documentation for sources of primary data pertaining to formaldehyde exposure and developmental and reproductive toxicity

#### Literature Search Results from the Systematic Evidence Map Update through 2021

Figure B-16 Reproductive and developmental effects literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Reproduction-and-Development/))

A total of 1,544 citations were retrieved for the assessment of reproductive and developmental effects and 9 studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

Of the 9 studies that met PECO criteria, five were deemed to be possibly impactful (see Table B-16). There were four from the human literature and one from the animal literature. Neither of the identified mechanistic studies were deemed possibly impactful. Wang et al. (2015) was identified in the literature search update and deemed possibly impactful, but it already had been included in the 2017 draft.

Table B-16 Studies of reproductive and developmental effects

Reference | Study design | Exposure^a^ | Endpoints | Impactful? | Rationale
Human Studies
Amiri and Turner Henson (2017) | General population southeastern U.S. cross-sectional | Air sampling, prenatal, exposure during pregnancy | Biparietal diameter, head circumference, abdominal circumference, femur length, ratio of abdominal circumference to femur length (AC/FL), estimated fetal weight | Possibly impactful | Key endpoints of concern for which there are few studies
Chang et al. (2017) | General population Seoul, South Korea birth cohort | Air sampling, prenatal, exposure during pregnancy | Birthweight, postnatal weight at 6, 12, 24, and 36 months. | Possibly impactful | Key endpoints of concern for which there are few studies
Franklin et al. (2019) | General population Australia birth cohort | Air sampling, prenatal, exposure during pregnancy | Gestational age, birth length, birth weight, head circumference | Possibly impactful | Key endpoints of concern for which there are few studies
Wang et al. (2015) | Occupational China cross-sectional | Air sampling and occupational history, adults, male plywood production workers | Semen volume, sperm concentration, total sperm count, sperm progressive motility and total sperm motility, curvilinear velocity, straight line velocity, linearity, time-average velocity, straightness, mean angular displacement, amplitude of lateral head displacement | Possibly impactful | Already identified in 2017 draft
Animal Studies^b^
Sapmaz et al. (2018) | Rat (Sprague Dawley), male Short-term (4 wk) or Subchronic (13 wk), 8 hr/d, 5 d/wk | Paraformaldehyde 0, 5 ppm (0, 6.15 mg/m^3^) Inhalation | Testicular tubular atrophy, germinative epithelium height, seminiferous tubule diameter; markers of ROS in testicular tissue | Possibly impactful | Longer duration study; informative morphological endpoints
Ge et al. (2020b) | Rat (Sprague Dawley), male Subchronic (8 wk) | Formalin 0, 0.5, 2.46, 5 mg/m^3^ Inhalation | Testicular seminiferous tubule histopathology and morphometry, SPO11 protein in testicular tissue | Not impactful | Formalin
Zang et al. (2017) | Mouse (C57BL/6), male Subchronic (60 d; 4 hr/d) | Formalin 0, 0.5, 5, 10 mg/m^3^ Inhalation | Sexual behavior (mount latency, intromission latency, ejaculation latency, mount frequency, intromission frequency, copulatory efficacy); hormone measures (serum T and LH; testicular T); sperm number and motility; reproductive organ weights and histopathology | Not impactful | Formalin
Mechanistic Studies
Fang et al. (2015) | Rat (Sprague Dawley), male Short-term (4 wk; 8 hr/d) | Unspecified test article 0, 0.5, 5, 10 mg/m^3^ Inhalation | mTOR (mammalian target of rapamycin, a regulator of various cellular processes) mRNA expression, protein levels, and immunostaining in testes | Not impactful | Unspecified test article
Ibrahim et al. (2016) | Rat (Wistar), female (dam) Gestational (GD1-21; 1 hr/d, 5 d/wk) | Unspecified test article 0, 0.92 mg/m^3^ Inhalation | Markers of ROS and inflammation in dam uterus at parturition; inflammation and immune parameters in offspring after PND30: BAL cell count and myeloperoxidase activity, lung cytokines and inflammatory markers; blood and bone marrow cell count | Not impactful | Unspecified test article

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

a Use of methanol-stabilized formalin was inferred in some studies based on study-specific description (e.g., 37% stock solution).

b Animal studies may include evaluation of mechanistic endpoints.

### B.2.9 Cancer

As detailed in Section 2.2.9 of the Toxicological Review, the review of the potential for carcinogenicity following formaldehyde exposure was performed separately for the following: (1) human studies of respiratory tract, lymphohematopoietic, or other cancers (including brain, lung, pancreatic, etc.); (2) experimental animal studies of respiratory tract (e.g., nasal) cancers; and (3) experimental animal studies of LHP cancers. Ultimately, studies on cancers of the respiratory tract or LHP system are discussed in the Toxicological Review, while human studies on other cancer types are documented in the Appendix B.3.9. The search strings are documented in Table B-17 (human studies), Table B-18 (animal studies of respiratory tract cancers), and Table B-19 (animal studies of LHP cancers). The corresponding literature search results through 2016 are documented in Figure B-17, Figure B-18, and Figure B-19, respectively. The corresponding literature search results through 2021 identified by the SEM are documented in Figure B-20, Figure B-21, and Figure B-22, respectively, with the SEM screening decisions documented in the subsequent sections.

#### Search Strings

##### Human Studies

Table B-17 Summary of search terms for carcinogenicity in humans

Database, search date | Terms
PubMed; No date restriction | “formaldehyde”[ Majr] AND (“neoplasms”[All Fields] OR “cancer”[All Fields] OR “leukaemia”[All Fields] OR “leukemia”[All Fields] OR “multiple myeloma”[ All Fields] OR (“multiple”[All Fields] AND “myeloma”[All Fields]) OR “multiple myeloma”[All Fields] OR “myeloma”[All Fields] OR “lymphoma”[All Fields] OR “nasopharyngeal neoplasms”[ All Fields] OR (“nasopharyngeal”[All Fields] AND “neoplasms”[All Fields]) OR “nasopharyngeal neoplasms”[All Fields] OR (“nasopharyngeal”[All Fields] AND “cancer”[All Fields]) OR “nasopharyngeal cancer”[All Fields] OR (“sinonasal” [All Fields] AND “neoplasms”[All Fields]) OR “neoplasms”[All Fields] OR “cancer”[All Fields] OR “oropharyngeal neoplasms”[ All Fields] OR (“oropharyngeal”[All Fields] AND “neoplasms”[All Fields]) OR “oropharyngeal neoplasms”[All Fields] OR (“oropharyngeal”[All Fields] AND “neoplasms”[All Fields]) OR “laryngeal neoplasms”[ All Fields] OR (“laryngeal”[All Fields] AND “neoplasms”[All Fields]) OR “laryngeal neoplasms”[All Fields] OR (“laryngeal”[All Fields] AND “cancer”[All Fields]) OR “laryngeal cancer”[All Fields]) AND (Epidemiol*[All Fields] OR “Case-control studies”[All Fields] OR “Cohort studies”[All Fields] OR “Follow-up studies”[All Fields] OR “Risk factors”[All Fields])
Web of Science; No date restriction Lemmatization “off” | TS=formaldehyde AND (TS=neoplasms OR TS=cancer OR TS=leukaemia OR TS=leukemia OR TS=multiple myeloma OR (TS=multiple AND TS=myeloma) OR TS=multiple myeloma OR TS=myeloma OR TS=lymphoma OR TS=nasopharyngeal neoplasms OR (TS=nasopharyngeal AND TS=neoplasms) OR TS=nasopharyngeal neoplasms OR (TS=nasopharyngeal AND TS=cancer) OR TS=nasopharyngeal cancer OR (TS=sinonasal AND TS=neoplasms) OR TS=oropharyngeal neoplasms OR (TS=oropharyngeal AND TS=neoplasms) OR TS=oropharyngeal neoplasms OR (TS=oropharyngeal AND TS=neoplasms) OR TS=laryngeal neoplasms OR (TS=laryngeal AND TS=neoplasms) OR TS=laryngeal neoplasms OR (TS=laryngeal AND TS=cancer) OR TS=laryngeal cancer) AND (TS=Epidemiol* OR TS=Case-control studies OR TS=Cohort studies OR TS=Follow-up studies OR TS=Risk factors)
ToxNet (Toxline and DART); No date restriction | Formaldehyde AND (neoplasms OR neoplasms OR cancer OR leukaemia OR leukemia OR “multiple myeloma” OR (multiple AND myeloma) OR myeloma OR lymphoma OR “nasopharyngeal neoplasms” OR (nasopharyngeal AND neoplasms) OR “nasopharyngeal neoplasms” OR (nasopharyngeal AND cancer) OR
English, not including PubMed | “nasopharyngeal cancer” OR (sinonasal AND neoplasms) OR “oropharyngeal neoplasms” OR (oropharyngeal AND neoplasms) OR “oropharyngeal neoplasms” OR (oropharyngeal AND neoplasms) OR “laryngeal neoplasms” OR (laryngeal AND neoplasms) OR “laryngeal neoplasms” OR (laryngeal AND cancer) OR “laryngeal cancer”) AND (Epidemiol* OR “Case-control studies” OR “Cohort studies” OR “Follow-up studies” OR “Risk factors”))

##### Animal Studies: Respiratory Tract Cancers

Table B-18 Summary of search terms for respiratory tract cancers in animals

Database, search date | Terms
PubMed; 04/15/2013; No date restriction | Formaldehyde [majr] AND (animal OR rodent OR rat OR mouse OR hamster) AND (nasal OR nose OR buccal OR larynx OR lung OR mouth OR pharynx OR sinus OR trachea) AND (cancer OR dysplasia OR neoplasia OR tumor OR carcinoma OR polyp OR cytotoxicity OR neoplastic OR promoter OR pathology OR toxicity) NOT (formalin test OR formaldehyde fixation OR formalin fixed OR formaldehyde fixed OR formalin-induced OR formaldehyde-induced)
Web of Science; 03/08/2013; No date restriction Lemmatization “off” | Formaldehyde (title) AND (animal OR rodent OR rat OR mouse OR hamster) AND (nasal OR nose OR buccal OR larynx OR lung OR mouth OR pharynx OR sinus OR trachea) AND (cancer OR dysplasia OR neoplasia OR tumor OR carcinoma OR polyp OR cytotoxicity OR neoplastic OR promoter OR pathology OR toxicity) NOT (formalin test OR formaldehyde fixation OR formalin fixed OR formaldehyde fixed OR formalin-induced OR formaldehyde-induced)

##### Animal Studies: Lymphohematopoietic Cancers

Table B-19 Summary of search terms for lymphohematopoietic cancers in animals

Database, search date | Terms
PubMed; 04/15/2013; No date restriction | Formaldehyde [majr] AND (leukemia OR lymphoma OR hemolymphoreticular) AND (animal OR rodent OR monkey) NOT (formalin test OR formaldehyde fixation OR formalin fixed OR formaldehyde fixed OR formalin-induced OR formaldehyde-induced)
Web of Science; 03/08/2013; No date restriction Lemmatization “off” | Formaldehyde (title) AND (leukemia OR lymphoma OR hemolymphoreticular) AND (animal OR rodent OR monkey) NOT (formalin test OR formaldehyde fixation OR formalin fixed OR formaldehyde fixed OR formalin-induced OR formaldehyde-induced) (topic)

#### Literature Search Results through 2016

##### Human Studies

Figure B-17 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and upper respiratory or lymphohematopoietic cancers in humans

##### Animal Studies: Respiratory Tract Cancers

Figure B-18 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and upper respiratory tract (nasal) cancers in animals

##### Animal Studies: Lymphohematopoietic Cancers

Figure B-19 Literature search documentation for sources of primary data pertaining to inhalation formaldehyde exposure and lymphohematopoietic (LHP) cancers in animals

#### Literature Search Results from the Systematic Evidence Map Update through 2021

##### Human Studies

Figure B-20 Human cancer literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Human-Cancer/))

A total of 1,555 citations were retrieved for the assessment of cancer in humans and 6 studies met the PECO criteria.

##### Animal Studies: Respiratory Tract Cancers

Figure B-21 Animal respiratory tract cancer literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Respiratory_tract_cancer_animal/))

A total of 705 citations were retrieved for the assessment of respiratory tract cancers in animals and 2 studies met the PECO criteria.

##### Animal Studies: Lymphohematopoietic Cancers

Figure B-22 Animal lymphohematopoietic cancer literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Lymphohematopoietic-cancer-animal/))

A total of 66 citations were retrieved for lymphohematopoietic cancers in animals and 2 studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

##### Human Studies

Of the six studies that met the PECO criteria (see Table B-20), one possibly impactful study, Checkoway et al. (2015), had already been included in the 2017 draft as reanalysis of the primary NCI cohort, and one not impactful study, Pira et al. (2014), had already been included in the 2017 draft. The four new studies that met the PECO criteria increased the total number of studies that met PECO in the searches through 2017 (n = 63) to a total of 67 studies that met PECO.

Table B-20 Studies of site-specific cancer in humans

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Humans
Checkoway et al. (2015) | Occupational United States cohort | Air sampling, occupational history, and job-exposure matrix, adults, NCI cohort reanalysis | Cause-specific mortality [non-Hodgkin lymphoma mortality, chronic lymphocytic leukemia mortality, Hodgkin lymphoma mortality, multiple myeloma mortality, myeloid leukemia mortality, acute myeloid leukemia mortality, chronic myeloid leukemia mortality, all leukemia mortality, lymphohematopoietic cancer mortality] | Possibly impactful | Already identified in 2017 draft
Marsh et al. (2016) | Occupational United States cohort | Air sampling, occupational history, and job-exposure matrix, adults, NCI cohort NPC reanalysis | Nasopharyngeal cancer mortality | Possibly impactful | Additional analyses of key endpoint of concer
Möhner et al. (2019) | Occupational United States cohort | Occupation-based, adults, NCI cohort analysis | Mortality from nasopharyngeal cancer [oropharynx, nasopharynx, hypopharynx, pharynx, pharynx (unspecified)] | Possibly impactful | Additional analyses of key endpoints of concern
Pira et al. (2014) | Occupational Piedmont, Italy cohort | Occupational history, adults, laminated plastics workers | Cause-specific mortality [lymphoma, myeloma, leukemia, all lymphatic and hematopoietic tissue neoplasms] | Not impactful | Already identified in 2017 draft
Sernia et al. (2016) | Occupational Italy cohort | Current occupation, adults, university laboratory workers | NPC, leukemia/lymphoma | Not impactful | Inadequate exposure assessment; NPC well-established
Xie et al. (2017) | General population Hong Kong case-control | Occupational history and industrial code, self-report, adults | Nasopharyngeal carcinoma incidence | Not impactful | Inadequate exposure assessment; health effect well-established

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

##### Animal Studies: Respiratory Tract Cancers

Of the two studies meeting the PECO criteria (see Table B-21), one was deemed possibly impactful. This study, (Morgan et al., 2017) had already been included in the 2017 draft; thus, zero (0) additional studies were included.

Table B-21 Animal studies of respiratory tract cancers

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Animal Studies
Morgan et al. (2017) | Mouse (Trp53 haploinsufficient), Male Subchronic (8 wk; 6 hr/d, 5 d/wk), then held for 32 wk | Paraformaldehyde 0, 7.5 or 15 ppm (0, 9.2, 18.5 mg/m^3^) Inhalation | Blood was collected for hematology, and major tissues and gross lesions were collected for histopathology (nasal and LHP cancer, and respiratory lesions) | Possibly impactful | Already included in 2017 draft
Soffritti et al. (2016) | Rat (SD), both sexes Chronic (continuous exposure from 6–104 wks of age) | Unspecified test article 0, 50 ppm Oral (drinking water) | Carcinogenicity study (presumed to include evaluation of nasal/URT tumors) | Not impactful | Oral exposure; high levels; formalin (note: would be screened as excluded, but inventoried due to rarity of chronic exposure duration studies of cancer)

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

##### Animal Studies: Lymphohematopoietic Cancers

Of the two studies that met the PECO criteria (see Table B-22), one was deemed possibly impactful. This study, (Morgan et al., 2017) had already been included in the 2017 draft; thus, zero (0) additional studies were included.

Table B-22 Animal studies of lymphohematopoietic cancer

Reference | Study design | Exposure | Endpoints | Impactful? | Rationale
Animal Studies
Morgan et al. (2017) | Mouse (Trp53 haploinsufficient), Male Subchronic (8 wk; 6 hr/d, 5 d/wk), then held for 32 wk | Paraformaldehyde 0, 7.5 or 15 ppm (0, 9.2, 18.5 mg/m^3^) Inhalation | All major tissues and gross lesions were collected for histopathology (including LHP tissues) | Possibly impactful | Already included in 2017 draft
Soffritti et al. (2016) | Rat (SD), both sexes Chronic (continuous exposure from 6–104 wks of age) | Unspecified test article 0, 50 ppm Oral (drinking water) | Carcinogenicity study (presumed to include evaluation of nasal/URT tumors) | Not impactful | Oral exposure; high levels; formalin (note: would be screened as excluded, but inventoried due to rarity of chronic exposure duration studies of cancer)

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

### B.2.10 Mechanistic Information Relevant to Cancer

As detailed in Section 2.2.10 of the Toxicological Review, consolidated systematic approaches to identifying the literature examining mechanistic effects relevant to interpreting the potential for formaldehyde to cause either upper respiratory tract (URT) or lymphohematopoietic (LHP) cancers were not performed. Rather, the evidence bases of identified studies was compiled from searches and evaluations performed for genotoxicity (see description below), respiratory tract pathology (see Appendix B.2.5), and mechanistic information related to noncancer respiratory effects, including inflammation and immune changes (see Appendix B.2.6), augmented by studies cited in review articles retrieved through searches on specific cancer types as well as other national-level health assessments. For genotoxicity, a consistent set of search terms was applied within electronic databases (i.e., PubMed and Web of Science) to address the broader topic of mode of action for either respiratory tract or LHP cancers. The retrieved citations were screened for studies on genotoxic endpoints. These broad search terms (Tables B-23 and B-24 for respiratory tract and LHP cancer mechanisms, respectively) were used to ensure capture of newer literature (e.g., published after the available national-level health assessments). The literature search results through 2021 identified by the SEM are documented in Figure B-23 (respiratory tract cancer-related mechanisms) and Figure B-24 (LHP cancer-related mechanisms), with the SEM screening decisions documented in the subsequent sections.

#### Search Strings

##### Mechanistic Studies for Respiratory Tract Cancers, Focusing on Genotoxicity

Table B-23 Search terms for cancer mechanisms of respiratory cancers

Mechanisms of Respiratory Tract Cancers Focusing on Genotoxicity - Pubmed
1 | (Formaldehyde[tiab] OR formaldehyde[mh])
2 | AND (nose[tiab] OR nasal[tiab] OR nasopharynx[tiab] OR nasopharyngeal[tiab] OR respiratory[tiab] OR bronchial[tiab] OR “upper respiratory”[tiab] OR mucociliary[tiab] OR mononuclear[tiab] OR “nasal mucosa”[tiab] OR “human bronchial”[tiab] OR “nasal cavity”[tiab] OR trachea[tiab] OR “oral mucosa”[tiab] OR lymphoblasts[tiab] OR “endothelial cells”[tiab] OR “respiratory tract”[tiab] OR olfactory[tiab] OR “nasal epithelia”[tiab] OR “nasal turbinates”[tiab] OR “nose”[mh] OR “nasopharynx”[mh] OR “trachea”[mh] OR “smell”[mh])
3 | AND (tumor[tiab] OR carcinoma[tiab] OR cancer[tiab] OR neoplastic[tiab] OR cytotoxic[tiab] OR cytotoxicity[tiab] OR proliferation[tiab] OR “cell proliferation”[tiab] OR immunosuppression[tiab] OR immune[tiab] OR genotoxicity[tiab] OR genotoxic[tiab] OR mutation[tiab] OR mutagenic[tiab] OR epigenomic[tiab] OR epigenetic[tiab] OR microRNA[tiab] OR “micro RNA”[tiab] OR methylation[tiab] OR “chromosome aberration”[tiab] OR “chromosomal aberration”[tiab] OR micronuclei[tiab] OR MN[tiab] OR micronucleus[tiab] OR “sister chromatid exchange”[tiab] OR SCE[tiab] OR “single strand break”[tiab] OR SSB[tiab] OR glutathione[tiab] OR oxidation[tiab] OR “oxidative damage”[tiab] OR inflammation[tiab] OR “DNA-protein crosslink”[tiab] OR DPX[tiab] OR “DNA adduct”[tiab] OR clastogen[tiab] OR clastogenicity[tiab] OR promotion[tiab] OR promoter[tiab] OR “DNA repair”[tiab] OR “immune activation”[tiab] OR phagocyte[tiab] OR macrophages[tiab] OR cytogenetic[tiab] OR “regenerative cell proliferation”[tiab] OR mutagenesis[tiab] OR “DNA-protein crosslinks”[tiab] OR “respiratory cancer”[tiab] OR “nasal cancer”[tiab] OR “immune function”[tiab] OR “immune biomarkers”[tiab] OR “respiratory disease”[tiab] OR DPC[tiab] OR DPX[tiab] OR “DNA damage”[tiab] OR irritation[tiab] OR bronchitis[tiab] OR “regenerative hyperplasia”[tiab] OR toxicological[tiab] OR adenomas[tiab] OR rhinitis[tiab] OR dysplasia[tiab] OR metaplasia[tiab] OR inhalation[tiab] OR carcinogen[tiab] OR “chromosomal damages”[tiab] OR “nasal carcinoma”[tiab] OR toxicology[tiab] OR toxicity[tiab] OR “DNA-DNA cross-link”[tiab] OR “respiratory epithelium”[tiab] OR SCC[tiab] OR “pathological changes”[tiab] OR “histopathological nasal changes”[tiab] OR cilia[tiab] OR “nasal lesions”[tiab] OR “protein oxidation”[tiab] OR “cellular immunity”[tiab] OR autoantibodies[tiab] OR tumour[tiab] OR “cell damage”[tiab] OR “neoplasms”[mh] OR “carcinoma”[mh] OR “immunosuppression”[mh] OR “immune tolerance”[mh] OR “mutation”[mh] OR “epigenomics”[mh] OR “methylation”[mh] OR “glutathione”[mh] OR “inflammation”[mh] OR “phagocytes”[mh] OR “macrophages”[mh] OR “cytogenetics”[mh] OR “mutagenesis”[mh] OR “nose neoplasms”[mh] OR “bronchitis”[mh] OR “adenoma”[mh] OR “rhinitis”[mh] OR “metaplasia”[mh] OR “inhalation”[mh] OR “carcinogens”[mh] OR “toxicology”[mh] OR “toxicity”[Subheading] OR “cilia”[mh] OR “autoantibodies”[mh] OR “immune system phenomena”[mh] OR “mutagens”[mh] OR “Cytotoxicity, Immunologic”[mh] OR “Cell Proliferation”[mh] OR “MicroRNAs”[mh] OR “Chromosome Aberrations”[mh] OR “Sister Chromatid Exchange”[mh] OR “DNA Breaks, Single-Stranded”[mh] OR “DNA Adducts”[mh] OR “Promoter Regions, Genetic”[mh] OR “DNA Repair”[mh] OR “Respiratory Tract Diseases”[mh] OR “DNA Damage”[mh] OR “Respiratory Mucosa”[mh] OR “Immunity, Cellular”[mh])
4 | NOT (“formalin test”[tiab] OR “formaldehyde fixation”[tiab] OR “formalin fixed”[tiab] OR “formaldehyde fixed”[tiab] OR formalin-induced[tiab] OR formaldehyde-induced[tiab])
Mechanisms of Respiratory Tract Cancers Focusing on Genotoxicity - WoS
1 | Formaldehyde (Title only)
2 | AND (nose OR nasal OR nasopharynx OR nasopharyngeal OR respiratory OR bronchial OR upper-respiratory OR mucociliary OR mononuclear OR nasal-mucosa OR human-bronchial OR nasal-cavity OR trachea OR oral-mucosa OR lymphoblasts OR endothelial-cells OR respiratory-tract OR olfactory OR nasal-epithelia OR nasal-turbinates)
3 | AND (tumor OR carcinoma OR cancer OR neoplastic OR cytotoxic OR cytotoxicity OR proliferation OR immunosuppression OR immune OR genotoxicity OR genotoxic OR mutation OR mutagenic OR epigenomic OR epigenetic OR microRNA OR micro-RNA OR methylation OR chromosome-aberration OR chromosomal-aberration OR micronuclei OR MN OR micronucleus OR sister-chromatid-exchange OR SCE OR single-strand-break OR SSB OR glutathione OR oxidation OR oxidative-damage OR inflammation OR DNA-protein-crosslink OR DPX OR DNA-adduct OR clastogen OR clastogenicity OR promotion OR promoter OR DNA-repair OR immune-activation-phagocyte OR macrophages OR cytogenetic OR regenerative-cell-proliferation OR mutagenesis OR DNA-protein-crosslinks OR respiratory-cancer OR nasal-cancer OR immune-function OR immune-biomarkers OR respiratory-disease OR DPC OR DPX OR DNA-damage OR irritation OR bronchitis OR regenerative-hyperplasia OR toxicological OR adenomas OR rhinitis OR dysplasia OR metaplasia OR inhalation OR carcinogen OR chromosomal-damages OR bronchitis OR nasal-carcinoma OR toxicology OR toxicity OR DNA-DNA-cross-link OR respiratory-epithelium OR SCC OR pathological-changes OR histopathological-nasal-changes OR cilia OR nasal-lesions OR protein-oxidation OR cellular-immunity OR autoantibodies OR tumour OR cell-damage)
4 | NOT (formalin-test OR formaldehyde-fixation OR formalin-fixed OR formaldehyde-fixed OR formalin-induced OR formaldehyde-induced)

##### Mechanistic Studies for Lymphohematopoietic (LHP) Cancers, Focusing on Genotoxicity

Table B-24 Mechanistic Studies for Lymphohematopoietic (LHP) Cancers, Focusing on Genotoxicity

Mechanisms of LHP Cancers Focusing on Genotoxicity - Pubmed
1 | (Formaldehyde[tiab] OR formaldehyde[mh])
2 | AND (blood[tiab] OR lymphocytes[tiab] OR “bone marrow”[tiab] OR hematopoietic[tiab] OR “hematopoietic stem cells”[tiab] OR leukocytes[tiab] OR “white blood cell”[tiab] OR “NK cell”[tiab] OR “natural killer cell”[tiab] OR b-lymphocyte[tiab] OR b-cell[tiab] OR t-lymphocyte[tiab] OR t-cell[tiab] OR leukemia[tiab] OR lymphoma[tiab] OR myeloid[tiab] OR serum[tiab] OR albumin[tiab] OR adduct[tiab] OR genotoxic[tiab] OR aneuploidy[tiab] OR pancytopenia[tiab] OR epigenomics[tiab] OR epigenetic[tiab] OR microRNA[tiab] OR “micro rna”[tiab] OR methylation[tiab] OR “chromosome aberration”[tiab] OR “chromosomal aberration”[tiab] OR micronucleus[tiab] OR “sister chromatid exchange”[tiab] OR glutathione[tiab] OR oxidation[tiab] OR “oxidative damage”[tiab] OR inflammation[tiab] OR dna-protein-crosslink[tiab] OR “dna adduct”[tiab] OR “immune activation”[tiab] OR “blood”[Subheading] OR “blood”[mh] OR “lymphocytes”[mh] OR “lymphocyte count”[mh] OR “bone marrow”[mh] OR “hematopoietic system”[mh] OR “hematopoietic stem cells”[mh] OR “leukocytes”[mh] OR “leukocyte count”[mh] OR “leukocytes”[mh] OR “killer cells, natural”[mh] OR “killer cells, natural”[mh] OR “b-lymphocytes”[mh] OR “b-lymphocytes”[mh] OR “tlymphocytes”[mh] OR “t-lymphocytes”[mh] OR “leukemia”[mh] OR “lymphoma”[mh] OR “serum”[mh] OR “albumins”[mh] OR “aneuploidy”[mh] OR “pancytopenia”[mh] OR “epigenomics”[mh] OR “epigenomics”[mh] OR “micrornas”[mh] OR “micrornas”[mh] OR “methylation”[mh] OR “chromosome aberrations”[mh] OR “chromosome aberrations”[mh] OR “sister chromatid exchange”[mh] OR “glutathione”[mh] OR “inflammation”[mh] OR “dna adducts”[mh])
3 | NOT (“formalin test”[tiab] OR “formaldehyde fixation”[tiab] OR “formalin fixed”[tiab] OR “formaldehyde fixed”[tiab] OR formalin-induced[tiab] OR formaldehyde-induced[tiab])
Mechanisms of LHP Cancers Focusing on Genotoxicity - WoS
1 | Formaldehyde (Title only)
2 | AND (blood OR lymphocytes OR bone-marrow OR hematopoietic OR hematopoietic-stem-cells OR leukocytes OR white-blood-cell OR NK-cell OR natural-killer-cell OR b-lymphocyte OR b-cell OR t-lymphocyte OR t-cell OR leukemia OR lymphoma OR myeloid OR serum OR albumin OR adduct OR genotoxic OR aneuploidy OR pancytopenia OR epigenomics OR epigenetic OR microRNA OR micro-rna OR methylation OR chromosomeaberration OR chromosomal-aberration OR micronucleus OR sister-chromatid-exchange OR glutathione OR oxidation OR oxidative-damage OR inflammation OR dna-protein-crosslink OR dna-adduct OR immuneactivation)
3 | NOT (formalin-test OR formaldehyde-fixation OR formalin-fixed OR formaldehyde-fixed OR formalin-induced OR formaldehyde-induced)

#### Literature Search Results from the Systematic Evidence Map Update through 2021

##### Mechanistic Studies for Respiratory Tract Cancers, Focusing on Genotoxicity

Figure B-23 Mechanistic respiratory tract cancer literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/Respiratory-tract-cancer-mechanistic/))

A total of 362 citations were retrieved for the assessment of mechanistic information informing respiratory tract cancers, focusing on genotoxicity, and 27 studies met the PECO criteria.

##### Mechanistic Studies for Lymphohematopoietic (LHP) Cancers, Focusing on Genotoxicity

Figure B-24 Mechanistic lymphohematopoietic cancer literature tree (interactive version here (https://hawcprd.epa.gov/summary/visual/assessment/100500053/LHP-cancer-mechanistic/))

A total of 2,356 citations were retrieved for the assessment of mechanistic information informing lymphohematopoietic cancers, focusing on genotoxicity, and 25 studies met the PECO criteria.

#### Screening for Inclusion from the 2021 Systematic Evidence Map Update

##### Mechanistic Studies for Respiratory Tract Cancers, Focusing on Genotoxicity

Of the 27 studies meeting PECO criteria, eight studies were deemed to be possibly impactful (note: one possibly impactful study is repeated under both the animal and in vitro/ex vivo sections). Table B-25 summarizes the SEM-identified studies of formaldehyde exposure in humans and animals, as well as in vitro or ex vivo experiments. Several studies relevant to endogenous formaldehyde, pharmacokinetic modeling and dosimetry also were included.

Table B-25 Mechanistic studies relating to respiratory tract cancers, focusing on genotoxicity

Reference | Study design | Exposure^a^ | Mechanistic endpoints | Impactful? | Rationale
Human Studies
Aglan and Mansour (2018) | Occupational; Cairo, Egypt; Cross-sectional | Air sampling; Adult hairstylists | Buccal cell MN frequency | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Costa et al. (2019) | Occupational Portugal; Cross-sectional | Air sampling; Adult anatomy-pathology laboratory workers | Buccal cell MN and nuclear budding, genotype analysis of selected polymorphisms | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Peteffi et al. (2015) | Occupational; Rio Grande do Sul, Brazil; Cross-sectional | Air sampling; Adult furniture workers | Micronucleus (MN) assay in buccal cells: nuclear buds, binucleated cells, Karyorrhexis | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Bono et al. (2016) | Occupational Piedmont; region, Italy; Cross-sectional | Air sampling; Adult plastic laminate workers | Malondialdehyde DNA adducts in swabbed nasal epithelial cells | Not impactful | Not key endpoint, adducts may or may not lead to more robust markers
Bruno et al. (2018) | Occupational; Rome, Italy; Cross-sectional | Air sampling; Adult pathology laboratory workers | Counts of multinucleated ciliated cells, Karyorrhexis, Hyperchromatic SNS from middle portion of the inferior turbinate | Not impactful | Not key endpoint, nuclear abnormalities are non-specific markers
Animal Studies
Leng et al. (2019) | Rat (Fischer 344), male; Short-term (28 d; 6 hr/d) | Deuterated formaldehyde (no methanol); 0, 1, 30, 300 ppb (1.23, 36.9, 369 mg/m^3^) [^13^CD_2_]-HCHO; Inhalation | DNA adducts in nose, lung (and other tissues) | Possibly impactful | Endpoints important to understanding dosimetry; low exposure levels
Zhao et al. (2020) | Mouse (BALB/c), male; Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin; 0, 3 mg/m^3^; Inhalation | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies from nose and lung | Possibly impactful | Impactful endpoints (Note: formalin, but less of a concern in POE)
Bernardini et (2020) | Mouse (Swiss), male; Short-term (4 wk; 4 hr/d, 5 d/wk) | unspecified test article; 0, 0.5, 1, 5, 10 ppm (0, 0.62, 1.23, 6.15, 12.3 mg/m^3^); Inhalation | MN, comet assay, and global methylation in lung | Not impactful | Unknown test article; no specific URT measures
Edrissi et al. (2017) | Rat (F344), male; Short-term (7, 14, 21, or 28 d; 6 hr/d) | [^13^C]-labeled formaldehyde; 0, 2 ppm (0, 2.46 mg/m^3^); Inhalation | FA-lysine adducts in nasal epithelium, lung, and trachea | Not impactful | Not key endpoint, adducts may or may not lead to more robust markers
In vitro/Ex vivo Studies
Zhao et al. (2020) | Mouse (BALB/c), male; Ex vivo primary lung and nose cells; Acute (1 hr) | Formalin; 0, 50, 100, 200, 400 μM; In media | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies | Possibly impactful | Impactful endpoints (note: formalin; in vitro)
Anandarajan et al. (2020) | Yeast (Schizosaccharomyces pombe), deletion strains; Short-term (3-5 d) | Formalin; 0, 0.2, 0.5, 1.25, 1.5, 1.75 mM; (Note: included due to conserved DNA repair pathways between yeast and humans, and potential relevance to human susceptibility) | Toxicogenomic profiling of pathways relating to formaldehyde detoxification and DNA repair–including homologous recombination and nucleotide excision repair | Not impactful | Non-mammalian; formalin; high dose
Chen et al. (2017) | Human immortalized bronchial epithelial cells; Acute (up to 6 hr) | Unspecified test article; 0, 0.5 mM; In media | Inhibition of chromatin assembly, formaldehyde-histone adducts, gene expression | Not impactful | Unknown test article; in vitro; endpoint well-established in vitro
Gonzalez-Rivera et al. (2020) | Human immortalized bronchial epithelial cells Acute (2 hr) | Paraformaldehyde; 0, 1 ppm (0, 1.23 mg/m^3^); In vitro gaseous exposure | Cell phenotypic alterations; DNA damage | Not impactful | In vitro; endpoint wellestablished in vitro
Juarez et al. (2018) | Human immortalized, osteosarcoma, fibroblast, or epithelial colorectal adenocarcinoma cells; Short-term (5 d; continuous) | Unspecified test article; 0, 20, 40, 60, 80, 100 μM; In media | genomic analysis; (Note: included due to analyses across multiple cell lines which might reflect genomic signatures relevant to exposure of URT cells) | Not impactful | In vitro; indirect measure; no cell lines specific to URT
Kang et al. (2016) | Yeast (Saccharomyces cerevisiae), deletion strains 5 or 15 generations of exposure | Unspecified test article; 0, 0.15, 0.3, 0.6 mM (Note: included due to conserved DNA repair pathways between yeast and humans, and potential relevance to human susceptibility) | Toxicogenomic profiling of pathways relating to RNA stability and DNA repair–including homologous recombination, single strand annealing, and post-replication repair | Not impactful | Non-mammalian; Unknown test article; high dose
Nazarparvar-Noshadi et al. (2020) | Human immortalized lung epithelial cells; Acute (24 hr; note: cytotoxicity up to 72 hr) | Unspecified test article; 0, 25, 50, 100, 150, 200, and 300 μM; In media | DNA damage (DNA ladder) and cytotoxicity/ apoptosis | Not impactful | Unknown test article; in vitro; endpoint well-established in vitro
Zhang et al. (2018a) | Human immortalized alveolar basal epithelial cells; Acute (24 hr) | Freshly prepared formaldehyde solution; 25 to 1,500 μM; In media | DNA damage; chromosome damage; micronucleus frequency; cytotoxicity | Not impactful | In vitro; endpoint well-established in vitro
Zhang et al. (2020a) | Human immortalized bronchial epithelial cells; Acute (3, 6, 12, 24 hr) | Formalin; 0, 5, 10, 20, 40, 80 μM; In media | DNA strand breaks; chromosome damage; DNA repair, ROS, and cell cycle markers | Not impactful | Formalin; in vitro; endpoint well-established in vitro
Zhang et al. (2020b) | Human Immortalized bronchial epithelial cells; Acute (24 hr) | Formalin; 0, 10, 40, 80 μM; In media | DNA damage - comet assay; apoptosis; mitochondria-mediated apoptosis; reactive oxygen species levels | Not impactful | Formalin; in vitro; endpoint well-established in vitro
Modeling, Endogenous Formaldehyde, and Other Studies
Campbell Jr et al. (2020) | Updated pharmacokinetic model developed here for formaldehyde dG adducts based on the previously developed models for formaldehyde DPX (Andersen et al., 2010); (Conolly et al., 2000). | | | Possibly impactful | Model potentially important to modeling dosimetry. (Note: discussed with regard to toxicokinetics, Section 3.1, and cancer dose-response, Section 5.2, not MOA analysis, Section 3.2.5)
Corley et al. (2015) | Excerpt from abstract: extended airway computational fluid dynamic (CFD) models of the rat and human were coupled with airway region-specific physiologically based pharmacokinetic (PBPK) tissue models to describe the kinetics of formaldehyde. Simulations of aldehyde no-observed-adverse-effect levels for nasal toxicity in the rat were conducted until breath-by-breath tissue concentration profiles reached steady state. Human oral breathing simulations were conducted using representative aldehyde yields from cigarette smoke. | | | Possibly impactful | Model potentially important to modeling dosimetry. (Note: discussed with regard to toxicokinetics, Section 3.1, and cancer dose-response, Section 5.2, not MOA analysis, Section 3.2.5)
Miller et al. (2017) | BBDR: Previously a computational fluid dynamics model was combined with a 2-stage clonal growth model to develop a MOA-based DR model. This paper reports changes that reflect a better understanding of populations of cells at risk of carcinogenic transformation in the pharynx, larynx and respiratory bronchiolar portions of the human respiratory tract and inclusion of basal cells in the pool of cells at risk. | | | Possibly impactful | Model potentially important to modeling dosimetry. (Note: discussed with regard to cancer dose-response, Section 5.2, not MOA analysis, Section 3.2.5)
Burgos-Barragan et al. (2017) | Mouse (C57BL/6 × 129SV hybrid background), WT or KO in ALDH2, FANCD2, or both (note: also included in vitro evaluations in human, chicken, and mouse cells) | No formaldehyde inhalation exposures (note: included since it evaluates essentiality of formaldehyde detoxification processes in normal function) | Genotoxicity (DNA damage response markers) in vitro and in vivo (various tissues) when formaldehyde detoxification pathways are disrupted | Not impactful | No formaldehyde inhalation (note: included in the assessment as a reference study for discussion of potential sources of susceptibility relating to formaldehyde detoxification)
Starr and Swenberg (2016) | Update to prior non-primary research perspectives on how to calculate cancer risk | | | Not impactful | Non-primary research (note: discussed in the assessment given prior engagement on the topic and inclusion in other assessments)
Yang et al. (2020) | Excerpt from abstract: the deposition rates from the linear regressions of CH_2_O, CH_5_N, C_2_H_6_O, C_2_H_4_O_2_, C_3_H_8_O, C_6_H_6_, C_7_H_8_, C_8_H_8_, and C_8_H_10_ of 120 healthy volunteers were obtained with significantly different from the respective calculated deposition rates. In order to explore the effects of the breathing models and sampling time on the deposition rates of VOCs, volunteers were first asked to breathe successively with nasal-in-nasal-out, oral-in-nasal-out, and oral-inoral-out breathing models before and after three meals for 3 d. In order to further validate the results, the deposition rates of the selected VOCs were calculated in 120 healthy volunteers using nasal-in-oral-out breathing model for unlimited time after the conventional lung function examination. | | | Not impactful | Not impactful to dosimetry modeling (note: briefly discussed in the assessment given use of human volunteers)
Yoo and Ito (2018a) | BBDR: PBPK-computational fluid dynamics hybrid analysis was integrated into the computer simulated person-based numerical simulation to estimate inhalation exposure and respiratory tissue dosimetry with the unsteady breathing cycle model. | | | Not impactful | Not impactful to dosimetry modeling (see below)
Yoo and Ito (2018b) | Excerpt from abstract: In this study, a CSP integrated with a virtual airway was developed and used to estimate inhalation exposure in an indoor environment. The virtual airway is a numerical respiratory tract model for CFD simulation that reproduces detailed geometry from the nasal/oral cavity to the bronchial tubes by way of the trachea. Physiologically based pharmacokinetic (PBPK)-CFD hybrid analysis is also integrated into the CSP. Through the coupled simulation of PBPK-CFD-CSP analysis, inhalation exposure under steady state conditions where formaldehyde was emitted from floor material was analyzed and respiratory tissue doses and their distributions of inhaled contaminants are discussed quantitatively. | | | Not impactful | Not impactful to dosimetry modeling; [Note: these studies by Yoo and Ito (Yoo and Ito, 2018a, b), extended the (Corley et al., 2015) modeling by superposing on it the dynamics of formaldehyde exterior to the respiratory tract (i.e. within the room and surrounding the nose and mouth). Thus, they do not provide additional information unavailable in (Corley et al., 2015) of relevance to the assessment]

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

Abbreviations: MN = micronucleus (assay); ROS = reactive oxygen species; BBDR = biologically based dose-response (model).

a Use of methanol-stabilized formalin was inferred in some studies based on study-specific description (e.g., 37% stock solution).

##### Mechanistic Studies for Lymphohematopoietic (LHP) Cancers, Focusing on Genotoxicity

Of the 25 studies meeting PECO criteria, 14 studies were deemed to be possibly impactful (see Table B-26). Studies relevant to pharmacokinetic modeling or dosimetry also were included. Mundt et al. (2017) was identified in the literature search update and included in the inventory table although it already had been included in the 2017 draft.

Table B-26 Mechanistic studies relating to lymphohematopoietic cancers, focusing on genotoxicity

Reference | Study design | Exposure^a^ | Mechanistic endpoints | Impactful? | Rationale
Human Studies
Aglan and Mansour (2018) | Occupational; Cairo, Egypt; Cross-sectional | Air sampling; Adult hairstylists | PBL MN | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Bassig et al. (2016) | Occupational Guangdong, China; Cross-sectional, | Air sampling; Adult formaldehyde factory workers | Frequency of monosomy 7 in isolated CFU-GM cells | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Costa et al. (2015) | Occupational; Northern and Central; Portugal; Cross-sectional | Air sampling; Adult pathology workers | Chromosomal aberrations, comet assay, genotype analysis in blood cells | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Costa et al. (2019) | Occupational; Portugal; Cross-sectional | Air sampling; Adult anatomy-pathology laboratory workers | PBL MN and sister chromatid exchange; T-cell receptor mutations; genotype analysis of select polymorphisms | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Mundt et al. (2017) | Occupational; China; Cross-sectional | Additional analysis of Zhang (2010) results; Adult factory workers | Monosomy of chromosome 7 and 8, complete blood count | Possibly impactful | Already identified in 2017 draft
Peteffi et al. (2015) | Occupational; Rio Grande do Sul, Brazil; Cross-sectional | Air sampling; Adult furniture workers | Comet assay in PBLs [cell migration, frequency of damaged cells, damage index] | Possibly impactful | Markers of DNA damage; exposure levels relevant to human cancer interpretations
Wang et al. (2019) | Occupational; Shanghai, China; Cross-sectional | Air sampling; Adult factory workers | Cytokinesis-blocked MN assay in PBLs | Possibly impactful | Specific markers; exposure levels relevant to human cancer interpretations
Zendehdel et al. (2017) | Occupational; Tehran City, Iran; Cross-sectional | Air sampling; Adult melamine workers | Comet assay [tail moment, Olive moment in PBLs] | Possibly impactful | Markers of DNA damage; exposure levels relevant to human cancer interpretations
Barbosa et al. (2019) | Occupational; Porto Alegre, Brazil; Cross-sectional | Air sampling; Adult beauty salon workers | Global DNA methylation (%) in PBLs | Not impactful | Note key endpoint, as not specific to genotoxicity
Zendehdel et al. (2018) | Occupational; Tehran, Iran; Cross-sectional | Air sampling; Adult melamine workers | DNA damage (comet assay) in PBLs | Not impactful | Related to Zendehdel et al. (2017), no additional results.
Animal Studies
Leng et al. (2019) | Rat (Fischer 344), male; Short-term (28 d; 6 hr/d) | Deuterated formaldehyde (no methanol); 0, 1, 30, 300 ppb (0, 1.23, 36.9, 369 μg/m^3^); Inhalation | DNA adducts in blood, bone marrow (and other tissues) | Possibly impactful | Endpoints important to dosimetry; low exposure levels
Liu et al. (2017) | Mouse (ICR), male; 20 wk (2 hr/d) | Unspecified test article; 0, 1, 10 mg/m^3^; Inhalation | Bone marrow cell MN; polychromatic erythrocytes (PCE)/normochromatic erythrocyte (NCE) ratio (immature/mature RBCs) | Possibly Impactful | Key endpoints of concern; longer duration study (note: presumed use of formalin limits interpretation)
Ma et al. (2020) | Mouse (Balb/c), male; Subchronic (8 wk; 8 hr/d, 7 d/wk) | Formaldehyde in water (methanol free); 0, 2 mg/m^3^; Inhalation | DNA damage (comet assay) in peripheral tissues (e.g., spleen; thymus); % of CD4+ T cells, CD8+ T cells, ratio of CD4+/CD8+ cells, and CD4 and CD8 cell phenotyping | Possibly impactful | Key endpoints of concern relevant to interpreting immune cell health and function
Aydemir et al. (2017) | Rat (Wistar albino), both sexes; Subchronic (6 wk; 8 hr/d, 5 d/wk) | Formalin; 0, 6 ppm (0, 7.38 mg/m^3^) Inhalation (note: i.p. deemed not PECO relevant) | DNA damage (comet assay) and ROS markers in peripheral blood | Not impactful | Formalin; high level
Bernardini et al. (2020) | Mouse (Swiss), male Short-term (4 wk; 4 hr/d, 5 d/wk) | unspecified test article; 0, 0.5, 1, 5, 10 ppm (0, 0.62, 1.23, 6.15, 12.3 mg/m^3^); Inhalation | MN, comet assay, and global methylation in blood and bone marrow | Not impactful | Unknown test article
Edrissi et al. (2017) | Rat (F344), male Short-term (7, 14, 21, or 28 d; 6 hr/d) | [13C]-labeled formaldehyde; 0, 2 ppm; Inhalation | FA-lysine adducts in bone marrow and WBCs | Not impactful | Not key endpoint, adducts may or may not lead to more robust markers
Ge et al. (2020a) | Mouse (Balb/c), male; Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin; 0, 0.5, 3 mg/m^3^; Inhalation | Myeloid progenitor cell (BFU-E and CFU-GM) colony counts and cytokines; bone marrow histology, ROS, and gene expression of cell cycle and DNA damage markers | Not impactful | Formalin; short-term (otherwise impactful endpoints)
Wei et al. (2017b) | Mouse (BALB/c), male; Short-term (2 wk; 8 hr/d, 5 d/wk) | Formalin; 0, 3 mg/m^3^; Inhalation | Bone marrow - myeloid progenitor formation assay, bone marrow cellularity | Not impactful | Formalin; short-term (otherwise impactul endpoints)
Wei et al. (2017a) | Mouse (BALB/c), male, Short-term (2 wk; 5 d/wk), followed by 7 d recovery | Formalin; 0, 3 mg/m^3^; Inhalation | Complete blood count, bone marrow histopathology, myeloid progenitor colony-forming cell assay, ROS and inflammatory markers, DNA-protein crosslinks | Not impactful | Formalin; short-term (otherwise impactful endpoints)
Zhao et al. (2020) | Mouse (Balb/c), male Short-term (2 wk; 8 hr/d, 5 d/wk); (note: ex vivo systemic tissues not PECO relevant) | Formalin; 0, 3 mg/m^3^ | Formation of burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) cellular colonies in bone marrow and spleen | Not impactful | Formalin; short-term (otherwise impactful endpoints)
Modeling, Endogenous Formaldehyde, and Other Studies
Burgos-Barragan et al. (2017) | Mouse (C57BL/6 × 129SV hybrid background), WT or KO in ALDH2, FANCD2, or both (note: also includes in vitro evaluations in human, chicken, and mouse cells) | No formaldehyde inhalation exposures (note: included since it evaluates essentiality of formaldehyde detoxification in normal processes) | Colony Forming Units (CFU) from bone marrow stem cells and progenitor cells | Possibly impactful | No formaldehyde inhalation but included as a reference study for discussion of potential sources of susceptibility relating to formaldehyde detoxification; cell production from bone marrow is a key endpoint of concern
Dingler et al. (2020) | Mouse (C57BL/6 background), ALDH2 and ALDH5 WT, single, and double KO, both sexes (note: also includes primary cultures of human PBLs, fibroblasts, and buccal cells not deemed PECO-relevant) | No formaldehyde inhalation exposures (note: included since it evaluates essentiality of formaldehyde detoxification processes in normal function) | Genotoxicity in peripheral blood cells and bone marrow (MN assay, SCE); bone marrow stem cell and progenitor cell quantification, lineage characterization, and B cell maturation; thymic development and cell lineage characterization; complete blood cell count, cell cycle profiling | Possibly impactful | No formaldehyde inhalation but included as a reference study for discussion of potential sources of susceptibility relating to formaldehyde detoxification; cell production from bone marrow is a key endpoint of concern
García-Calderón et al. (2018) | Mouse (C57BL/6 background), WT or KO in ALDH5 or FANCD2 (note: also includes in vitro evaluations not deemed PECO-relevant) | No formaldehyde inhalation exposures (note: included since it evaluates essentiality of formaldehyde detoxification in normal processes) | Bone marrow HSPC lineage, function, and genotoxicity; complete blood cell count | Possibly impactful | No formaldehyde inhalation but included as a reference study for discussion of potential sources of susceptibility relating to formaldehyde detoxification; cell production from bone marrow is a key endpoint of concern
Nakamura et al. (2020) | Mouse (C57BL/6 background), ALDH2 and ALDH5 WT, single, and double KO, both sexes Observed GD0 to PND25 | No formaldehyde inhalation exposures (note: included since it evaluates essentiality of formaldehyde detoxification processes in normal function) | Postnatal survival and gross organ observations (e.g., spleen, liver, lung thymus) | Not impactful | No formaldehyde inhalation and not key endpoint of concern (note: included as a reference study for discussion of potential sources of susceptibility relating to formaldehyde detoxification)
Starr and Swenberg (2016) | Update to prior non-primary research perspectives on how to calculate cancer risk | | | Not impactful | Non-primary research (note: discussed in the assessment given prior engagement on the topic and inclusion in other assessments)

Abbreviations: PBL = peripheral blood leukocytes; MN = micronucleus; WBC = white blood cell.

Rows for studies judged as “not impactful” are shaded gray; unshaded rows highlight studies incorporated into the assessment.

a Use of methanol-stabilized formalin was inferred in some studies based on study-specific description (e.g., 37% stock solution).

## B.3 STUDY EVALUATION

General approaches used in the identification and evaluation of individual studies are summarized in Section 2.3 of the Toxicological Review, with additional details outlined under each of the evaluated hazards. Because formaldehyde exposure-related issues were a significant concern in this assessment, a separate description of the considerations for judging exposure assessments in observational epidemiology studies is included in the Toxicological Review and documented as part of the health outcome-specific evaluations in the Appendix sections below. All experimental studies considered for use in hazard identification, including controlled exposure studies in both humans and animals, were separately evaluated to assess the quality of the inhalation exposure protocols (documented in Section B.3.1 below).

### B.3.1 Exposure Quality Evaluations

Typical human exposures to formaldehyde can be complex and difficult to translate to experimental systems. Experimental exposure to formaldehyde by inhalation is typically achieved through volatilization of formalin or depolymerization of paraformaldehyde. Methanol, present in aqueous formaldehyde solutions to inhibit polymerization, is a potential confounder of associations between observed health outcomes and formaldehyde exposure via formalin. Thus, the test article used to generate the formaldehyde atmosphere in experimental studies was critically evaluated, including consideration of whether a methanol-only control group was used.^2^ Based on the assumption that most labs used commercially available formalin for convenience, the test article is assumed to be formalin (and is documented as such) if the test article was not reported. Inhalation study uncertainties or limitations are shaded for easy recognition. A study’s exposure quality may be upgraded if a study author provides key missing data. Each study was subjectively ranked as having Good, Adequate, or Deficient exposure characterization based upon the number and severity of the uncertainties and limitations identified, defined as follows:

- Good Exposure Characterization: There are no notable uncertainties or limitations regarding exposure methodology.
- Adequate Exposure Characterization: There are minor uncertainties or limitations regarding exposure methodology.
- Deficient Exposure Characterization: There are serious uncertainties or limitations regarding exposure methodology.

The details of the evaluation approach methods are provided in Section 2.3.1 of the Toxicological Review. Within the tables below documenting the results of the exposure quality evaluations, studies are arranged alphabetically within each ‘Good’, ‘Adequate’, or ‘Deficient’ rating grouping. The results of these evaluations are included as one domain evaluated for experimental studies in humans or animals to classify confidence (see Appendix B.3.2 to B.3.10 below).

Table B-27 Inhalation exposure quality: formaldehyde (Note: exposure deficiencies are shaded)

Study/species | Test article characterization and controls | Generation method | Analytical method | Analytical concentrations | Particle size | Chamber description
Good Exposure Characterization: there are no notable uncertainties or limitations regarding exposure methodology
Adams et al. (1987); Mouse | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Ahmed et al. (2007); Mouse | Paraformaldehyde | NR | HPLC | Reported | NA | Dynamic whole-body
Albert et al. (1982); Rat; See Sellakumar et al. (1985) | Paraformaldehyde | — | — | — | — | —
Andersen et al. (2010); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Appelman et al. (1988); Rat | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Babiuk et al. (1985); Rat | Paraformaldehyde (and 7 other aldehydes) | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Bach et al. (1990); Human; [Exposure parameters are inferred from coauthor using same climate chamber in Anderson and Mølhave, Andersen and Molhave (1983)] | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic “climate chamber”
Barrow (1983); Mouse and Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry and colorimetric method | Reported | NA | Dynamic head-only
Battelle (1981) See (Kerns et al., 1983) | Paraformaldehyde | — | — | — | — | —
Berglund and Nordin (1992); Human | Freshly prepared formalin from paraformaldehyde (no methanol) | Evaporation | IR spectrophotometry; sodium bisulfite method; acetyl acetone method | Reported | NA | Dynamic olfactomer
Berglund et al. (2012); Human | Freshly prepared formalin from paraformaldehyde (no methanol) | Evaporation | IR spectrophotometry; acetyl acetone method | Reported | NA | Dynamic olfactometer
Casanova et al. (1994); Rat | Paraformaldehyde, [^14^C]-paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Cassee et al. (1996b); Cassee et al. (1996a); Rat | Freshly prepared formalin from paraformaldehyde (no methanol) and/or acetaldehyde, acrolein | Evaporation | Formaldehyde analyzer | Reported | NA | Dynamic nose-only
Cassee and Feron (1994); Rat | Freshly prepared formalin from paraformaldehyde (no methanol). Exposures were to PFA only, ozone only, or to both chemicals | Evaporation | IR spectrophotometry | Reported | NA | Dynamic nose-only
Chang et al. (1981); Rat and mouse | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry and colorimetric method | Reported | NA | Dynamic head-only
Chang et al. (1983); Rat and mouse | Paraformaldehyde and [^14^C]-paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body and head-only
See also Kerns et al. (1983); (Battelle, 1982) | Paraformaldehyde | — | — | — | NA | —
Coon et al. (1970); Rat, guinea pig, rabbit, dog, monkey | Freshly prepared formalin (paraformaldehyde added to hot distilled water; 1.35% solution) | Spray nozzle and evaporation of solution | IR analyzer equipped with a catalytic oxidizer | Reported | NA | Dynamic whole-body
Dalbey (1982); Hamster | Paraformaldehyde | Thermal depolymerization | Colorimetric analysis | Within 5% of target | NA | Dynamic whole-body
Dallas et al. (1989); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Day et al. (1984); Human | UFFI off-gas products | Broken-up UFFI foam was dampened with water, then gases collected in 4500 L polyethylene balloons. | Chromotropic acid | Reported | NA | Dynamic whole-body
Dean et al. (1984); Mouse | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic wholebody
Dinsdale et al. (1993); Rat; Experiment 2 (See also Experiment 1-Inadequate) | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Feron et al. (1988); Rat | Paraformaldehyde | Thermal depolymerization | Colorimetric | Reported | NA | Dynamic whole-body
Fujimaki et al. (2004b); Mouse | Paraformaldehyde | NR | HPLC | Reported | NA | Dynamic whole-body
Green et al. (1987); Human | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Green et al. (1989); Human | Paraformaldehyde | Thermal depolymerization | Colorimetric monitor | Reported | NA | Dynamic whole-body
Groten et al. (1997); Rat | Paraformaldehyde alone or in combination with dichloromethane, aspirin, di(2-ethylhexyl)-phthalalate, cadmium chloride, stannous chloride, butyl hydroxyanisol, loperamide, and spermine | Vaporization of freshly made formalin | Colorometric method | Reported (sampled in the animals’ breathing zone) | NA | Dynamic whole-body
Hayashi et al. (2004); Mouse | Paraformaldehyde | Thermal depolymerization | HPLC | Reported | NA | Dynamic whole-body
Holmstrom et al. (1989b); Rat | Paraformaldehyde with and without wood dust | Thermal depolymerization | Formaldehyde meter | Reported | NA | Dynamic whole-body
Jakab (1992); Mouse | Paraformaldehyde; exposure was to formaldehyde gas with or without carbon black aerosol | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Kamata et al. (1997); Rat | Formalin with 10% methanol A methanol control group was used | Sprayed into a bottle heated to 70°C | Acetylacetone | Reported for formaldehyde and methanol | NA | Dynamic nose-only
Swenberg et al. (1980a); Kerns et al. (1983); Battelle (1982); Rat and mouse | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Kulle et al. (1987); Human | Paraformaldehyde (reference provided) | Thermal depolymerization | Toxic gas monitor, chromotropic acid | Reported | NA | Dynamic whole-body
Kulle (1993); Human | Paraformaldehyde (reference provided) | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Kuper et al. (2011); Rat | Probably freshly prepared formalin (10.21% formaldehyde) | NR | IR spectrophotometry | Reported | NA | Dynamic whole-body
Larsen et al. (2013); Mouse | Polyacetal (a formaldehyde polymer) in permeation tubes | Permeation tube in a Kin-Tek gas standard generator | HPLC | Reported | NA | Dynamic head-only
Martin (1990); Rat | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Monteiro-Riviere and Popp (1986); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Monticello et al. (1991); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Monticello et al. (1996); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Monticello and Morgan (1997); Rat; Based on Monticello et al. (1996) | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Morgan et al. (1986a); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | ±5% of nominal | NA | Dynamic head-only
Morgan et al. (1986c); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic whole-body
Müller et al. (2012); Human | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor, HPLC | Reported | NA | Dynamic whole-body
Mueller et al. (2013); Human | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor HPLC | Reported | NA | Dynamic whole-body
Ozen et al. (2002); Rat | Paraformaldehyde | Thermal depolymerization | Gas chromatography and formaldehyde monitor | Reported | NA | Dynamic whole-body
Reuzel et al. (1990); Rat | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor | Reported | NA | Dynamic whole-body
Riedel et al. (1996); Guinea pig | Formaldehyde gas | Pressurized bottles | Photometric | Reported (in animals’ breathing zone) | NA | Dynamic whole-body
Roemer et al. (1993); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophometry | Within 10% of nominal | NA | Dynamic head-only
Rusch et al. (1983); Rat, monkey, hamster | Freshly prepared formalin (unstabilized 5% solution with 0.03% methanol) | Air was bubbled through formalin | Chromotropic acid | Reported | NA | Dynamic whole-body
Saldiva et al. (1985); Rat | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Sauder et al. (1986); Human | Paraformaldehyde (reference provided) | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Sauder et al. (1987); Human | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Sellakumar et al. (1985) and Albert et al. (1982); Rat | Paraformaldehyde; exposure to formaldehyde and/or HCl. Co-exposure to formaldehyde and HCl forms bis(chloromethyl)-ether (BCME), a carcinogenic reaction product. | A slurry of PFA in paraffin oil (kerosene) was generated by thermal depolymerization. HCl was from a compressed gas tank. | PFA: Chromotropic acid; HCl: titration with NaOH; BCME: gas chromatography/mass spectrometry | Reported [NOTE: HCl is a powerful catalyst for the polymerization of formaldehyde into oligomers (Bevington and Norrish, 2012). Unlike formaldehyde gas, oligomer particles may be respirable] | NA | Dynamic whole-body
Sheppard et al. (1984); Human | Freshly prepared formalin from paraformaldehyde (methanol-free) | Air was bubbled through formalin | IR spectrophotometry | Reported | NA | Respiratory valve mouthpiece
Songur et al. (2003); Rat | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor | Reported | NA | Dynamic whole-body
Songur et al. (2008); Rat | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor | Reported | NA | Dynamic whole-body
Sorg et al. (2001a); Rat; [Cited exposure parameters from Sorg et al. (1998)] | Paraformaldehyde | Thermal depolymerization | Photoacoustic multi-gas monitor | Reported | NA | Dynamic whole-body
Swenberg et al. (1980b) See Kerns et al. (1983)) | Paraformaldehyde | — | — | — | NA | —
Swiecichowski et al. (1993); Guinea pig | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Tobe et al. (1985b); Tobe et al. (1985a); [Study report]; Rat | Formalin (w/10% methanol) A methanol control group was used | Sprayed into a heated glass bath | Acetylacetone | Reported for formaldehyde and methanol | NA | Dynamic whole-body
Tsukahara et al. (2006); Mouse | Paraformaldehyde | NR | HPLC | Reported | NA | Dynamic whole-body
Usanmaz et al. (2002); Mouse | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | Reported | NA | Dynamic Not described
Vosoughi et al. (2013); Mouse | Paraformaldehyde | Thermal depolymerization | Photoionization detector | Reported | NA | Dynamic
Wood and Coleman (1995); Mouse | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported. Animals were able to stop irritating formaldehyde exposure | NA | Dynamic whole-body
Woutersen et al. (1987); Rat | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Reported | NA | Dynamic whole-body
Woutersen et al. (1989); Rat | Paraformaldehyde | Thermal depolymerization | Colorimetric | Reported | NA | Dynamic whole-body
Zeller et al. (2011); Human | Paraformaldehyde | Thermal depolymerization | HPLC and formaldehyde monitor | Reported | NA | Dynamic whole body
Zitting et al. (1982); Rat | Polyacetal plastic (Delrin®) | Oxidative thermodegradation (250°C) to formaldehyde, formic acid, and acrolein | Visible absorption spectrometry (NIOSH, 1972) | Reported | NA | Dynamic whole-body
Zwart et al. (1988); Rat | Paraformaldehyde | Thermal depolymerization (Woutersen et al., 1987) | Colorimetric | Reported | NA | Dynamic whole-body (reference provided)
Adequate Exposure Characterization: there are minor uncertainties or limitations regarding exposure methodology.
Andersen (1979); also described in Andersen and Mølhave (1983); Human | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Within 20% of target | NA | Dynamic whole-body
Andersen et al. (2008); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry, HPLC | Reported (≈30% variation in atmospheres) | NA | Dynamic whole-body
Andersen and Molhave (1983) [book chapter]; Human | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | Within 20% of target | NA | Dynamic “climate chamber”
Apfelbach and Weiler (1991); Rat | Paraformaldehyde | Thermal depolymerization | HPLC | NR | NA | NR; Exposures in plexiglas holding cages
Aslan et al. (2006); Rat | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor | NR; “Desired concentrations were prepared” | NA | Dynamic whole-body
Bender et al. (1983); Human | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | NR | NA | Dynamic smog chamber with 7 sets of ports
Boja et al. (1985); Rat | Paraformaldehyde | Thermal depolymerization | Gas chromatography | NR | NA | Dynamic whole-body
Chang and Barrow (1984); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry and colorimetric method | NR | NA | Dynamic head-only
Fujimaki et al. (2004b); Mouse; [Exposure parameters in Fujimaki et al. (2004a)] | Paraformaldehyde | NR; (Secondary source not found) | Formaldehyde monitor | NR | NA | Dynamic whole-body
Holmstrom et al. (1989a); Rat | Paraformaldehyde | Thermal depolymerization | NR | Reported | NA | Dynamic whole-body
Horton et al. (1963); Mouse | Paraformaldehyde | Thermal depolymerization | Method of Goldman and Yagoda (reference provided) | NR | NA | Dynamic whole-body
Ito et al. (1996); Rat | Formalin w/13% methanol A methanol control group was used | Formalin was placed in 50°C diffusion tubes | 4-amino-3-hydrazino-5-mercapto-1,2,4-triazole method analytical method for methanol NR | Reported; NR for methanol | NA | Dynamic (not described)
Kulle and Cooper (1975); Rat | Paraformaldehyde | Thermal depolymerization | Chromotropic acid | NR | NA | Dynamic olfactometer
Lang et al. (2008); Human | Paraformaldehyde (and ethyl acetate as a masking agent) | Thermal depolymerization | Dinitrophenylhydrazine andHPLC analysis Formaldehyde monitor | Reported | NA | “Quasi static conditions”
Meng et al. (2010); Rat | Paraformaldehyde | Thermal depolymerization | IR Spectrophotometry | NR | NA | Dynamic (not described)
Moeller et al. (2011); Monkey | [^13^CD_2_]-formaldehyde | NR | NR | Reported | NA | Dynamic whole-body
Monticello et al. (1989); Monkey | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | NR | NA | Dynamic whole-body
Morgan et al. (1984); Frog | Paraformaldehyde An ex vivo study of frog palates exposed to formaldehyde gas | Thermal depolymerization | IR spectrophotometry and colorimetric assay | Within 20% of nominal | NA | This is not an inhalation chamber study
Nielsen et al. (1999); Mouse | Paraformaldehyde | Thermal depolymerization | NR | NR | NA | Dynamic whole-body
Morgan et al. (2017); Mouse | Paraformaldehyde | Thermal depolymerization | Formaldehyde meter | NR | NA | Dynamic whole-body
Ozen et al. (2003a); Rat | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor | NR | NA | Dynamic whole-body
Ozen et al. (2003b); Rat | Paraformaldehyde | Thermal depolymerization | Gas chromatography and formaldehyde monitor | NR | NA | Dynamic whole-body
Ozen et al. (2005); Rat | Paraformaldehyde | Thermal depolymerization | Formaldehyde monitor | NR | NA | Dynamic whole-body
Sari et al. (2004); Mouse | Paraformaldehyde | NR; (Secondary source not found) | “a chemical method” and Formtector XP-308 | Reported | NA | Dynamic whole-body
Sari et al. (2005); Mouse; Cited exposure parameters from Sari et al. (2004) | Paraformaldehyde (Mice were exposed intranasally to 500 ppm toluene/mouse 6 hr/d for 3 da prior to formaldehyde exposure) | NR; (Secondary source not found) | “measured chemically” and Formtector XP-308 | Reported | NA | Dynamic whole-body
Sari et al. (2005); Mouse | Paraformaldehyde | NR; (Secondary source not found) | “measured chemically” and Formtector XP-308 | Reported | NA | Dynamic whole-body
Sarsilmaz et al. (1999); Rat | Paraformaldehyde | Thermal depolymerization (reference provided) | Formaldehyde monitor | NR | NA | Dynamic whole-body
Sarsilmaz et al. (2007); Rat; [Assumed to be the same cohort as Aslan et al. (2006)] | Paraformaldehyde | Thermal depolymerization (reference provided) | Formaldehyde monitor | NR; “Desired concentrations were prepared” | NA | Dynamic “prism-shaped glass covers”
Schachter et al. (1986a); Human | Paraformaldehyde (apparent co-exposure to 2-propanol) | Thermal depolymerization over boiling 2-propanol | Chromotropic acid | Reported | NA | Dynamic whole-body
Schachter et al. (1987); Human | Paraformaldehyde (apparent co-exposure to 2-propanol) | Thermal depolymerization over boiling 2-propanol | Chromotropic acid | Reported | NA | Dynamic whole-body
Sorg et al. (1998); Rat | Paraformaldehyde | Thermal depolymerization | HPLC | Reported 44% decline in concentration over the course of the experiment | NA | Dynamic whole-body
Sorg et al. (2001b); Rat; Experiment 2 and 3 (See also Experiment 1-Inadequate) | Paraformaldehyde | Thermal depolymerization | HPLC; (Sorg et al., 1998) | NR | NA | Dynamic whole-body
Sorg et al. (2004); Rat | Paraformaldehyde with co-exposure to orange oil (a known irritant) | Thermal depolymerization | Photoacoustic multi-gas monitor | Reported | NA | NR
Sorg and Hochstatter (1999); Rat; Experiment 2 (See also Experiment 1-Inadequate) | Paraformaldehyde | Thermal depolymerization | HPLC; (Sorg et al., 1998) | NR | NA | Dynamic whole-body
Wilmer et al. (1987); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | NR | NA | Dynamic whole-body
Wilmer et al. (1989); Rat | Paraformaldehyde | Thermal depolymerization | IR spectrophotometry | NR | NA | Dynamic Whole-body
Witek et al. (1986); Human | Paraformaldehyde (apparent co-exposure to 2-propanol) | Thermal depolymerization over boiling 2-propanol (82.5°C) | Chromotropic acid | Reported | NA | Dynamic whole-body
Witek et al. (1987); Human | Paraformaldehyde (apparent co-exposure to 2-propanol) | Thermal depolymerization over boiling 2-propanol (82.5°C) | Chromotropic acid | Reported | NA | Dynamic whole-body
Deficient Exposure Characterization: there are serious uncertainties or limitations regarding exposure methodology.
Al-Saraj (2009); Rabbit | 10% Formalin No methanol control [Pretreatment with Ivermectin which can cause cleft palate and clubbed forelimbs in rabbits] | Evaporation | Colorimetric method (based on a reference); Methanol not measured | Reported (12 ppm) | NA | Dynamic whole-body
Amdur (1960); Guinea pig | Formalin (37%) | Sintered glass bubbler | Colorimetric method and chromotropic acid | Reported | NaCl particles measured | Dynamic whole-body
Arican et al. (2009); Rat | Paraformaldehyde | Thermal depolymerization | NR | NR | NA | Dynamic whole-body
Bansal et al. (2011); Rabbit | 10% Formalin; 40% Formalin; No methanol control | Evaporation from open containers | NR | NR; Target and nominal concentrations also NR | NA | Open containers of formalin were placed below cages
Biagini et al. (1989); Monkey | Formalin w/10-15% methanol; No methanol control [Anesthesia with ketamine and xylazine, which cause bronchodilation, could affect pulmonary function measurements.] | Injected into a GC injector and heated to 220-230°C | Formaldehyde monitor; Methanol not measured | Reported | NA | Dynamic whole-body
Bian et al. (2012); Rat | Formalin; No methanol control | Evaporation | Formaldehyde meter; Methanol not measured | 10.0 ± 1.0 mL/m^3^ | NA | Dynamic whole-body
Bhalla et al. (1991); Rat | Paraformaldehyde | Thermal depolymerization | NR | NR | NA | Dynamic nose-only
Bokina et al. (1976); Rabbit | NR; No methanol control | NR | NR | NR | NA | NR
Buckley et al. (1984); Mouse | Formalin; (co-exposure to methanol) No methanol control | NR | IR spectrophotometry; Methanol not measured | Reported | NA | Dynamic whole-body
Casset et al. (2006); Human | Formalin; (35% aqueous medicinal solution of formaldehyde; co-exposure to methanol) No methanol control | Evaporated from a Pyrex boiler at 85°C | HPLC; Methanol not measured | <10% of target | NA | Dynamic whole-body with subjects wearing masks
Chonglei et al. (2012); Mouse | Mice were simultaneously exposed to formaldehyde, benzene, toluene, and xylene vapors. The test article for formaldehyde was NR | NR | Digital electrochemical analyzer and gas chromatography | NR | NA | Dynamic whole-body (airflow not reported)
Cometto-Muñiz and Hernández (1990); Human | NR; No methanol control | NR | Chromotropic acid | Reported | NA | Dynamic olfactometer
Day et al. (1984); Human | Solution of formalin in methanol.; No methanol control | Atomized and then evaporated on a hot plate. | Chromotropic acid; Methanol not measured | Reported | NA | Dynamic whole-body
de Ceaurriz et al. (1981); Mouse | NR; No methanol control | NR | Colorimetric method; Methanol not measured | NR | NA | Dynamic whole-body
Dinsdale et al. (1993); Rat; Experiment 1 (See also Experiment 2 - Good) | Formalin; (co-exposure to methanol); No methanol control | Jet atomizer (Exp 1) | IR spectrophotometry; Methanol not measured | Reported | NA | Dynamic whole-body
Ezratty et al. (2007); Human | Formalin; (co-exposure to methanol); No methanol control | Thermal depolymerization | Semiconductor gas sensor; Methanol not measured | NR | NA | Dynamic whole-body
Falk et al. (1994); Human | Formalin; (co-exposure to methanol) No methanol control. | Evaporation from a heated glass surface | Liquid chromatography | Reported for treated and negative control groups | NA | Dynamic Whole-body
Gieroba et al. (1994); Rabbit | 38% Formalin; No methanol control | Evaporation | None | NR | NA | A tube delivered FA vapor to rabbits’ nares
Gofmekler (1968); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | NR
Gofmekler and Bonashevskaya (1969); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | NR
Golalipour et al. (2007); Rat | NR but exposure would have been to formalin with co-exposure to methanol; No methanol control | NR, but formaldehyde and methanol would have offgassed from necropsy tubs of formalin | Formaldehyde Draeger tubes Methanol not measured | Reported | NA | Not a chamber study; rats exposed in dissection room
Guseva (1973b); Rat | NR; No methanol control | NR; Rats were simultaneously exposed by inhalation and drinking water | Fuchsin sulfurous acid method; Methanol not measured | NR | NA | Dynamic (not described)
Han et al. (2015); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | Static
Harving et al. (1990); Human | Alkaline solution of formalin; co-exposure to methanol; No methanol control | Thermal depolymerization | Acetylacetone; Methanol not measured | Reported | NA | Dynamic whole-body
Silva Ibrahim et al. (2015); Rat | Formalin (purity NR) A vehicle control group was exposed to water No methanol control | Ultrasonic nebulizer | NR | NR | 0.5-1 μm; MMAD NR | Dynamic whole-body
Ionescu et al. (1978); Rabbit | NR; (probably aerosolized formalin); No methanol control | NR | NR; Methanol not measured | NR; (target and nominal concentrations also NR) | NA | Static
Jaeger and Gearhart (1982); Mouse and Rat | Formalin; No methanol control | Aerosolization and evaporation | IR spectrophotometry and colorimetric method; Methanol not measured | Reported | NA | Dynamic whole-body (Mason jar)
Kamata et al. (1996b); Rat | Formalin (with 10% methanol); No methanol control | Sprayed into a bottle heated to 70°C | Acetylacetone; Methanol not measured | Reported | NA | Dynamic whole-body
Kamata et al. (1996a); Rat | Formalin with 10% methanol; No methanol control | Sprayed into a bottle heated to 70°C | Acetylacetone; Methanol not measured | Reported | NA | Dynamic nose-only
Kane and Alarie (1977); Mouse | Formalin; No methanol control | Evaporation | Colorimetric method; Methanol not measured | Reported | NA | Dynamic head-only
Katsnelson et al. (2013); Rat | NR; No methanol control | NR | NR; Methanol not measured | Reported | NA | Dynamic whole-body
Kimura et al. (2010); Rat | 37% Formalin with 15% methanol; No methanol control | Dynamic gas generator (evaporation) | 4-amino-3-hydrazino-5-mercapto-1,2,4-triazole method; Methanol not measured | NR | NA | Dynamic whole-body
Kim et al. (2013b); Mouse | NR; No methanol control | NR | HPLC | NR | NA | NR
Kitaev et al. (1984); Rat | NR; No methanol control | NR | Gravimetric (not described) Methanol not measured | NR | NA | Dynamic; (not described)
Krakowiak et al. (1998); Human | 10% Formalin; No methanol control | Evaporation | Chromotropic acid; Methanol not measured | Reported | NA | Dynamic whole-body
Kum et al. (2007a); Kum et al. (2007b); Rat | Formalin; No methanol control | NR | Gas detection pump (reference provided); Methanol not measured | NR | NA | Dynamic whole-body
Lee et al. (1984); Guinea pig | 4% Formalin w/1% methanol 37% formalin w/10% methanol No methanol control | Aerosol generated by a nebulizer | Formaldehyde: chromotropic acid Methanol: IR spectrophotometry | NR for formaldehyde or methanol | NR | Dynamic whole-body
Liao et al. (2010); Rat | Formalin; No methanol control | NR | Formaldehyde meter; Methanol not measured | NR | NA | Static
Lino dos Santos Franco et al. (2006); Rat | Formalin (diluted to 1%; with 0.32% methanol) A methanol control group was used. | Ultrasonic nebulizer | NR for formaldehyde or methanol | NR for formaldehyde or methanol (nominal concentration NR) | NR | Dynamic whole-body
Lino dos Santos Franco et al. (2009); Rat | Formalin; No methanol control | Ultrasonic nebulizer | NR | NR; Methanol not measured | NR | Dynamic (probably whole-body)
Lino-Dos-Santos-Franco et al. (2011b); Rat | Formalin (diluted to 1%; with 0.32% methanol); No methanol control | Ultrasonic nebulizer | NR | NR; Methanol not measured | NR | NR
Liu et al. (2009a); Rat | Formalin (37%); No methanol control | Evaporation from the inner walls of the static chamber | Formaldehyde monitor | Reported | NA | Static
Liu et al. (2010); Rat | Formalin (37%); No methanol control | Evaporation from the inner walls of the static chamber | Formaldehyde monitor | Reported | NA | Static
LICM (2006); Mouse | Wood baseboard (not described); co-exposure to unidentified chemicals | NR | NR | NR | NA | Dynamic; Not described
Maiellaro et al. (2014); Rat | Formalin (source and purity NR) The vehicle control was exposed to water | Ultrasonic nebulizer | NR; Methanol not measured | NR; Note: one exposure level tested | Reported | Dynamic
Malek et al. (2003c) Malek et al. (2003a) Malek et al. (2003b); Rat | Formalin; No methanol control | Evaporation from a dish in the chamber | Formaldehyde Draeger tubes Methanol not measured | Reported | NA | Static with holes
Malek et al. (2004); Mouse | Formalin; No methanol control | Evaporation from a dish in the chamber | Formaldehyde Draeger tubes Methanol not measured | Reported | NA | Static with holes
Maronpot et al. (1986); Mouse | Formalin (9.2%w/v); No methanol control | Nebulization and evaporation | Chromotropic acid | Reported | NA | Dynamic whole-body
Matsuoka et al. (2010); Mouse | Formalin; No methanol control | Evaporation | Cosmos^®^ smell sensor | NR | NA | Dynamic whole-body
Monfared (2012); Mouse | NR; No methanol control | NR | NR | NR | NA | Dynamic whole-body
Morgan (1983); Rat | Paraformaldehyde (reference provided) | Thermal depolymerization | NR | NR | NA | Dynamic whole-body
Nalivaiko et al. (2003); Rabbit | Paraformaldehyde | Thermal depolymerization | None | NR | NA | A tube delivered formaldehyde vapor to rabbits’ nares
Ohtsuka et al. (1997); Rat | NR; No methanol control | Aerosol generated by an atomizer | NR; Methanol not measured | NR | NR | Dynamic whole-body “test room”
Ohtsuka et al. (2003); Rat | 1% Formalin; No methanol control | Aerosol generated by an atomizer | NR; Methanol not measured | NR | NR | Dynamic whole-body “test room”
Pazdrak et al. (1993); Human | NR; No methanol control | NR | IR spectrophotometry | Reported | NA | Dynamic whole-body
Pitten et al. (2000); Rat | Formalin; No methanol control | Evaporation from a dish in the chamber | Acetylacetone method and photometric evaluation; Methanol not measured | Reported | NA | Static
Pross et al. (1987); Human | Formalin; No methanol control | Evaporation of formalin aerosol | Formalin: chromotropic acid; Methanol not measured | NR | NA | Dynamic whole-body
Pross et al. (1987); Human | Milled UFFI particles (4 μm) contaminated with heavy microbial growth | UFFI aerosol generation not described | UFFI aerosol: gravimetric filters and an aerodynamic particle sizer | NR | NA | Dynamic whole-body
Pross et al. (1987); Human | UFFI off-gas products. | UFFI off-gas generated by passing air through beds of fractured UFFI wetted with water | NR | NR | NA | Dynamic whole-body
Pushkina et al. (1968); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | NR
Sadakane et al. (2002); Mouse | Formalin (0.5% solution in saline; No methanol control | Aerosol generated by an ultrasonic nebulizer | NR; Methanol not measured | NR | NR | NR
Saillenfait et al. (1989); Rat | Formalin w/10% methanol; No methanol control | Air was bubbled through formalin | IR spectrophotometry Methanol not measured | Reported | NA | Dynamic
Sandikci et al. (2007b); Rat | NR; No methanol control | NR | NR; (reference provided); Methanol not measured | NR | NA | Dynamic whole-body
Sandikci et al. (2009); Rat | NR; No methanol control | NR | Formaldehyde Draeger tubes | NR | NA | Dynamic whole-body
Sanotskii et al. (1976); Rat | NR; No methanol control | NR | Colorimetry (not described) Methanol not measured | NR | NA | Dynamic (not described)
Schreiber et al. (1979); Hamster | NR; No methanol control | NR | NR | NR | NA | NR
Schuck et al. (1966); Human | Formaldehyde and other photooxidation products | Formaldehyde was generated during propylene photooxidation and ethylene photooxidations in a reaction chamber exposed to high intensity UV light (3,000 Å) | Chromotropic acid | Mean concentrations provided in a graph | NA | Reaction chamber with welding masks attached for eye exposure
Senichenkova (1991b); Rat | NR; No methanol control | NR | Gravimetric (not described); Methanol not measured | NR | NA | Dynamic (not described)
Senichenkova and Chebotar (1996b); Rat | NR; No methanol control | NR | Gravimetric (not described); Methanol not measured | NR | NA | Dynamic (not described)
Sheveleva (1971); Rat | NR; No methanol control | NR | NR; (reference provided); Methanol not measured | Reported | NA | Dynamic whole-body
Sorg et al. (1996); Rat | Formalin; No methanol control | Air was bubbled through formalin | NR; Methanol not measured | Reported | NA | Dynamic whole-body
Sorg et al. (2001b); Rat; Experiment 1 (See also Experiments 2 and 3-Adequate) | Formalin; No methanol control | Evaporation of formalin | NR; Methanol not measured | NR | NA | Dynamic whole-body
(Sorg et al., 2002); Rat | Formalin; No methanol control | Evaporation | None | NR | NA | Cotton swabs containing various formalin dilutions were placed in a maze
Sorg and Hochstatter (1999); Rat; Experiment 1 (See also Experiment 2-Adequate) | Formalin; No methanol control | Air was bubbled through formalin | NR | NR | NA | Dynamic whole-body
Speit et al. (2011b); Rat | Formalin; No methanol control | Evaporation | NR; Methanol not measured | Reported | NA | Dynamic whole-body
Swenberg et al. (1983b) [book chapter]; Rat and Mouse | [^14^C]- formaldehyde | NR | NR | NR | NA | NR
Swenberg et al. (1986) [book chapter]; Rat and Mouse | NR; No methanol control | NR | NR | NR | NA | NR
Tani et al. (1986); Rabbit | 37% Formalin; No methanol control | Evaporation | 4-amino-3-hydrazino-5mercapto-1,2,4-triazole method; Methanol not measured | NR | NA | Direct exposure to the upper and lower respiratory tract via two Ttubes
Tepper et al. (1995); Mouse | Carpet containing volatile organic compounds, pesticide residues, and microbiological flora | Heating of carpet | Gas chromatography High resolution mass spectrometry | Reported for formaldehyde and 9 other specific organic chemicals | NR | Dynamic head-only
Tarkowski and Gorski (1995); Mouse | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | NR
Wang et al. (2012); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | Static; (not otherwise described)
Weber-Tschopp et al. (1977); Human | Formalin (35%); No methanol control | A syringe delivered formalin to a heated (120°C) Pyrex glass tube | Chromotropic acid; Methanol not measured | Reported | NA | Dynamic whole-body
Xing Sy (2007); Mouse | NR; No methanol control | NR | NR | NR | NA | NR
Yang et al. (2001); Human | Plywood (5 layers) which off-gassed formaldehyde and traces of C_6_–C_11_ aldehydes. | The plywood was cut into 50- × 10-cm planks and placed in a small chamber to facilitate off-gassing. | Formaldehyde monitor | Reported for formaldehyde, but location of measures NR; concentrations of other gases NR | NA | Eyes were exposed via modified swim goggles
Yorgancilar et al. (2012); Rat | NR; No methanol control | NR | NR | NR | – | NR
Yu and Blessing (1997); Rabbit | 38% Formalin; No methanol control | Evaporation | None | NR | NA | A tube delivered formaldehyde vapor to rabbits’ nares
Yu and Blessing (1999); Rabbit | NR; No methanol control | NR | None | NR | NA | formaldehyde vapor puffed in front of the rabbits’s nares
Zhang et al. (2013); Mouse | Formalin (10%); No methanol control | NR | NR | NR | NA | Dynamic nose-only
Zhang et al. (2014b); Rat | Formalin; No methanol control | Evaporation | NR | Reported but questionable | NA | Static
Zhou et al. (2006); Rat | NR; No methanol control | NR | Formtector; Methanol not measured | NR | NA | NR
Zhou et al. (2011a); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | Static
Zhou et al. (2011b); Rat | NR; No methanol control | NR | NR; Methanol not measured | NR | NA | Static

HPLC – high performance liquid chromatography; IR – infrared; MMAD (σ_g_) – mass median aerodynamic diameter (geometric standard deviation); NA – Not applicable; NR – not reported; PFA – paraformaldehyde.

### B.3.2 Sensory Irritation

The details of the study evaluation approach methods are provided in Section 2.3.2 of the Toxicological Review. Within Tables B-28 (residential studies), B-29 (school-based studies) B-30 (controlled exposure studies), B-31 (anatomy course studies), and B-32 (occupational studies) below documenting the results of the study evaluations for sensory irritation, studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating.

#### Residential Studies

Table B-28 Evaluation of studies examining sensory irritation in humans: residential studies

Reference, setting and design | Consideration of participant selection and compar-ability | Exposure measure and range | Outcome measure | Consideration of likely con-founding | Analysis and completeness of results | Size | Confidence
Bracken et al. (1985) (Ontario) Residential (prevalence) | Exposed homes randomly selected from a group currently being monitored for formaldehyde and previously at homeowner request. Participant selection likely based on exposure and outcome status. | Area samples; average of 3 hr samples; 5 per home.; UFFI Mean 0.07, max 0.13 mg/m^3^; non-UFFI Mean 0.06, max 0.12 mg/m^3^; Lab Mean 0.15, max 7.2 mg/m^3^. Details of sampling protocol not provided. Most samples may have been below LOD (NIOSH, 1977, chromotropic) | Self-report, ATS question-naire. Response was not blinded to presence of UFFI. | Exposed: Homes with UFFI, Referent: non-UFFI homes from university community; age and smoking prevalence similar. | Symptom prevalence estimated from graphs in Figures 1 and 2 in publication. Compared prevalence by exposure group, ttest | N = 54 exposed; N = 26 referent | Not Informative Participant selection likely based on exposure and outcome status; Small exposure contrast (formaldehyde concentration similar in comparison groups); potential for exposure status to affect outcome classification
Dally et al. (1981) (Wisconsin) Residential (prevalence) | Survey of homes reported to State Division of Health because of symptoms; Participant selection potentially based on exposure and outcome status. | Area samples; average of 30–60 min samples in multiple locations. LOD 0.12 mg/m^3^ Mobile homes, Median 0.58, range <0.12 to 4.53 mg/m^3^. Conventional, Median 0.12, range <0.12 to 1.34 mg/m^3^. | Self-report, questionnaire. Responses blind to formaldehyde measurements. | No comparison group; smoking status was not associated with formaldehyde concentration; no adjusted results provided | Symptom prevalence among exposed | N = 256 | Not Informative No comparison group; Participant selection potentially based on exposure and outcome status, limited statistical analyses
Hanrahan et al. (1984) (Wisconsin) Residential (prevalence) | Recruited from a randomly selected list of mobile homes in Wisconsin; response rate 31%. Formaldehyde concentrations, age, and gender were comparable to a subsample of nonrespondents who did not return the health questionnaire, and participants blinded to formaldehyde concentration. Differential participation in the study based on symptom severity is unknown but cannot be ruled out. | Area samples; average of 1-hr samples from 2 rooms. Median 0.2 mg/m^3^, range <0.12 to 0.98 mg/m^3^; Adequate contrast.; Details of sampling provided: closed residence with no point formaldehyde emissions; sampling and analytic protocols referenced (NIOSH chromotropic acid method); Quality control conducted; lowest measurement was 0.12 mg/m^3^ (LOD was not stated, but even lower concentrations were measured in outdoor air. Temperature and relative humidity were recorded. | Self-report, questionnaire, no description. Response blind to formaldehyde measurements. Symptoms ascertainment period (since moving into homes) did not correspond to exposure measurement period. | Logistic regression adjusting for age, gender, and smoking status. Gas appliances were turned off and smoking was not permitted during the sampling period. | Logistic regression, provided graph of predicted mean prevalence normalized to mean age, and upper and lower 95% CI by concentration from regression model. QC analysis showed no sample contamination. Smoking was found to not increase exposure concentration. | N = 61 | Medium Low participation rate, but exposure and demographic characteristics were comparable among respondents and nonrespondents to the health questionnaire. Differential participation in the study based on symptom severity is unknown but cannot be ruled out. Uncertainty regarding correspondence of one hour exposure measurement with period for symptom ascertainment (years); Questionnaire not described but outcomes reported without knowledge of formaldehyde levels.
Liu et al. (1991) (California) Residential (prevalence) | Recruited from a randomly selected, age-stratified list of mobile homes in California; response rate 44%. Uncertainty regarding differential or nondifferential selection based on knowledge of exposure or symptoms. | Area samples using passive monitors; 7-d average in 2 rooms in 2 seasons. Mean summer 0.089 ppm, winter 0.088 ppm; TWA concentration estimated using average concentration multiplied by # hours spent in the home per day during the week of sampling.; Validity study (Sexton et al., 1986) reported LOD of 0.01 ± 0.30 ppm; range, LOD - 0.57 mg/m^3^ | Self-report, mailed questionnaire, no description. Responses blind to formaldehyde measurements. Appropriate time frame relative to exposure measurements. | Logistic regression adjusting for age, gender, smoking status, status of chronic respiratory disease/allergy. | Logistic regression, beta coefficients for change in symptom prevalence per concentration change were not provided. Prevalence estimated from graph of prevalence by category of formaldehyde TWA exposure in publication. | N = 836 homes, 1,096–1,394 individuals | Medium Questionnaire not described but outcomes reported without knowledge of formaldehyde levels. Low participation rate but uncertain whether possible selection bias, if any, was nondifferential or differential.
Lovreglio et al. (2009) (prevalence) | Selection of 59 homes in city. Uncertainty regarding participant recruitment process or participation rate. | 24 hr samples in kitchen in 59 homes; reported mean, median, range. | Self-report, questionnaire (onset of symptoms while in kitchen). No description of questionnaire but responses likely not related to exposure status. | Formaldehyde and acetaldehyde concentrations were correlated (p = 0.001). Formaldehyde concentrations varied by smoking status. Data analyses not described, no adjustment or stratification. | No data provided, qualitative results only. | N = 182 subjects living in 59 homes | Not Informative Results of data analysis were not provided; confounding by smoking or coexposure was not addressed. Questionnaire was not described but responses likely not related to exposure status. Uncertainty regarding participant recruitment process or participation rate.
Main and Hogan (1983) (prevalence) | 21 exposed individuals working in 2 mobile trailers for 34 mo. 18 referent staff members who did not work in the trailers. Uncertainty regarding participant recruitment process or participation rate. | Three 1-hr area samples using impingers taken on 4 occasions (August, September, December, April) always on a Monday. At least 1 sample was taken from each office in both trailers. Concentration range: 0.15–1.97 mg/m^3^ Details of sampling provided: closed residence with no point formaldehyde emissions; sampling and analytic protocols referenced; referent group assumed to have no exposure. | Self-report, ATS questionnaire, symptom history at work. Responses among exposed likely not blinded to exposure status. | Groups were comparable for smoking history, race, and SES. Exposed were older (mean age 38) with more men (76%) compared to referents (mean age 30, 50% males). Potential dissimilarity of administrative employees and police officers (healthier); direction of bias possibly away from null; more exposure to ETS among referent; possible direction toward null. | Symptom prevalence at work compared between exposed and referent, chisquare; small sample size. | Exposed N = 21, Referent N = 18 | Low Potential dissimilarity between comparison groups; more exposure to ETS among referent; small sample size with increased potential for unreliable results. Uncertainty regarding participant recruitment process or participation rate. Responses among exposed likely not blinded to exposure status.
Norsted et al. (1985) (Texas) Residential (prevalence) | Homes selected on request of residents; Potential selection based on exposure and outcome status. | Sampling protocols not described | Self-report; symptom reports not blind to exposure status | No comparison group; no adjusted results provided | Total # participants in homes unknown. | N = 443 mobile homes | Not Informative Potential selection based on exposure and outcome status.; Reporting deficiencies, no comparisons
Olsen and Dossing (1982) (Denmark) Day care center workers in mobile homes (prevalence) | Recruited from all newly built mobile day care centers in 2 boroughs (n = 7) and 3 referent centers selected at random; response rates 94% exposed, 76% referent. Responses similar in exposed and referent to 3 questions not expected to be related to formaldehyde. | Area samples; average of 2-hr samples in 2–4 locations, on 1 occasion.; Exposed mean 0.43, range 0.24 to 0.55 mg/m^3^; referent mean 0.08, range 0.05 to 0.11 mg/m^3^; Details of sampling provided: closed residence with no point formaldehyde emissions; sampling and analytic protocols referenced | Self-report, questionnaire; linear analogue scale for severity, experience within one month; questionnaire described, and citation provided. Less certainty regarding characterization of average formaldehyde concentrations corresponding to outcome measurements in last month. | Referent selected from stationary child-care facilities in same residentia area. Age and smoking prevalence similar in exposed and referent. | Prevalence and severity presented in graphs; comparisons between exposed and referent groups. | Exposed N = 66; Referent N = 26 | Medium Some uncertainties regarding temporal concordance of exposure (< 1 d) and symptom assessments (within last month), but not expected to be substantial. Sample size in referent group small.
Ritchie and Lehnen (1987); (Minnesota) Residential (prevalence) | Selection into survey at request of family physician; potential selection based on exposure and outcome status. | Area samples; average of 30-min samples in 2 rooms.; Bedroom mean: Mobile homes 0.43 mg/m^3^, Conventional 0.15 mg/m^3^, range 0.012 (LOD) to 6.79 mg/m^3^.; Details of sampling provided: closed residence with no point formaldehyde emissions; sampling & analytic protocols referenced see also Ritchie and Lehnen (1985) | Self-report, interview; symptoms same day as exposure measurements, no description of questionnaire, but respondents did not know the formaldehyde measurement for their homes | Prevalence stratified by age, gender, and smoking status. | Presented graphs of prevalence by exposure (3 categories); tables of prevalence (SE) by type of home, exposure category, and smoking status | N = 2,000 residents; 891 homes | Low (↑) Potential selection based on exposure and outcome status. No description of questionnaire, but respondents did not know the formaldehyde measurement for their home
Salonen et al. (2009) (Finland) (prevalence) | Building selected because of complaints and symptom reports of occupants; potential selection based on exposure and outcome status | Area sampling in 20 of 176 buildings selected from database of Finnish Institute of Occupational Health, 2001–2006, N = 1–12 per building; during work hours 9–4 pm for 1–2 hrs. LOD 0.5 ppb Mean 0.011 mg/m^3^; Max 0.044 mg/m^3^. | Self-report, standardized questionnaire; Indoor Air Questionnaire (citation provided). Responses solicited in reference to identified air quality problems. | No comparison buildings evaluated. Compared concentrations to recommended indoor limit (RIL) | Presented ratio of average concentration divided by recommended indoor limit (based on RD50 for respiration rate in mouse bioassay and adjustment to 24 hrs based on Haber’s Law. | N = 20 buildings | Not Informative Potential selection based on exposure and outcome status; outcome responses were not blinded; no comparison group
Thun et al. (1982) (prevalence) | No information to evaluate | No formaldehyde measurements | Self-report, no description of questionnaire; new symptoms over a 1 year period. | Exposed: Homes with UFFI, Referent: homes without UFFI. No information to compare exposed and referent | Data were not provided, qualitative results with p-values | N = 1,396 exposed, 1,395 referent | Not Informative Inadequate reporting detail; no formaldehyde measurements
Zhai et al. (2013) Jan 2008–Dec 2009 (China) (prevalence) | Provided criteria for selection of homes in defined area (2008–2009); evaluated 186 homes in Shenyang, China; homes were decorated in last 4 years and occupied within the last 3 years. | Cited Code for indoor environmental pollution control of civil building engineering (GB50325-2001); sampling duration not reported. Samplers in breathing zone in bedroom, living room and kitchen; N = 558 in 186 homes; exposure groups polluted homes: > 0.08 mg/m^3^, mean 0.09–0.13 mg/m^3^ in 3 rooms; nonpolluted ≤0.08 mg/m3, mean 0.04–0.047 mg/m^3^. | Respiratory symptoms via questionnaire by interview (ATS, 1978); randomly selected one adult from each house, plus 82 children (assisted by parents); timing of questionnaire administration in relation to air monitoring uncertain. | Regression analyses of combined respiratory symptoms were adjusted; Prevalence ratios for specific symptoms/disorders unadjusted for other variables, characteristics in 2 groups not described; | Compared symptom prevalence for children and adults by exposure category (reported p-values); multivariate logistic regression of respiratory system symptoms (all) in children and adults, adjusting for age, gender, smoking in family, occupation, education, ventilation frequency, domestic pets, house facing, family history of allergy, height, weight. | Polluted homes N = 119; Non-polluted homes N = 67 | Analysis of combined respiratory symptoms Medium Sampling duration not reported; timing of questionnaire administration in relation to air monitoring uncertain.; Symptom prevalence ratios Medium Sampling duration not reported; timing of questionnaire administration in relation to air monitoring uncertain. Although potential confounders were not considered in symptom-specific analysis, the magnitude of the differences is unlikely to be explained by confounders.

#### School-based Studies

Table B-29 Evaluations of studies examining sensory irritation in humans: school-based studies

Reference setting and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Wantke et al. (1996a) (Austria) Schools (panel, intervention) | Children at school where symptoms were reported; evaluated all children attending 3 forms. | Area samples; Sample number and duration not described; s.d. not reported. Concentration in 3 grades: Before move: 0.053, 0.085, 0.092 mg/m^3^; After move: 0.036, 0.028, 0.032 mg/m^3^ | Symptoms assessed before and 3 mos after a move to a different school building. Symptoms reported by parents in a standardized questionnaire. Participants and investigators not blinded. | Comparison to self before and after removal from exposure | Symptom prevalence before and after move; McNemar test of difference | N = 62 | Not Informative; Participants and investigators not blinded; Reporting deficiencies

#### Controlled Exposure Studies in Humans

In addition to including shading (as described above for epidemiology studies), the controlled exposure studies in humans include italicized aspects of the study design or analysis highlight less significant limitations that had a minor impact on confidence classifications.

Table B-30 Evaluations of studies examining sensory irritation in humans: controlled human exposure studies

Reference and Confidence | Exposure assessment (details on exposure quality evaluation in Appendix B.3.1) | Outcome classification | possible bias (randomized exposure order, blinding to exposure) | Consideration of likely confounding | Results presentation | Size
Andersen (1979); Andersen and Molhave (1983)^a^; Confidence: Medium | Paraformaldehyde, dynamic chamber, analytical concentrations reported as within 20% of target; 0.24, 0.4, 0.81, 1.61 mg/m^3^; Adequate | Self-report, questionnaire; symptom scores | Random assignment to order of exposure, blinding not described. 31.2% smokers. | Within person comparison | Provided prevalence | N = 16
Bender et al. (1983); Confidence: Low | Paraformaldehyde, dynamic chamber, analytical concentrations not reported; 0, 0.43, 0.69, 0.86, 1.11, 1.23 mg/m^3^; Adequate | Self-report response (eye only), time to 1st response | Order of exposure assignment not described, blinding not described | Within person comparison | Provided prevalence | N = 7
Berglund et al. (2012); Confidence: Medium | Paraformaldehyde, analytical concentrations reported; series of 18, 0.0078–1.23 mg/m^3^;; Good | Nasal irritation (< 3 sec sniffs); Self-report, forced choice response Emphasis on threshold for detection, less direct relevance to symptom severity. | Exposure concentrations randomly presented; blinding not described. | Within person comparison | Graph of detection prevalence by ln concentration | N = 31
Cometto-Muñiz and Hernández (1990); Not informative | Test article NR, analytical concentrations reported; 1.23, 4.31, 8.49, 20.5 mg/m^3^; [underlined: Deficient] | “Pungency” symptoms (includes irritant and non-specific symptoms) from 2.5 sec sniffs; self-report | “Irregular order” of exposure presentation (but not random), blinding not described, healthy nonsmokers | Within person comparison | Graph of perceived intensity (alone or in combination with ammonia) | N = 28
Day et al. (1984); Not informative | Marginal; no clean air exposure, 1.23 mg/m^3^; Deficient | Self-report, questionnaire | Nonrandom exposure assignment, blinding not described | No comparisons | Provided prevalence | N = 18
Green et al. (1987); Confidence: High | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0, 3.69 mg/m^3^; Good | Self-report, questionnaire including nonirritant sham symptoms to assess bias; symptom severity scores | Random assignment to order of exposure, single blinded. | Within person comparison | Provided prevalence & statistical analyses | N = 22
Green et al. (1989); Confidence: High | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0, 3.69 mg/m^3^; Good | Self-report, questionnaire including nonirritant sham symptoms to assess bias; symptom severity scores | Random assignment to order of exposure, double blinded. | Within person comparison | Provided score data and statistical analyses graphically | N = 24
Krakowiak et al. (1998); Not informative | Formalin, no methanol control; analytic concentrations reported; 0.5 mg/m^3^; Deficient | Self-report, diary; symptom scores | Nonrandom exposure assignment, single blinded. | Within person comparison | Provided average symptom scores | 2 groups. N = 10 in each
Kulle et al. (1987); Kulle (1993)^a^; Confidence: Medium | Paraformaldehyde, dynamic chamber, analytical concentrations reported; I: 0, 0.62, 1.23, 2.46, II: 0, 1.23, 3.69 mg/m^3^; Good | Self-report, questionnaire; symptom scores | Random assignment to order of exposure, blinding not described. | Within person comparison | Regression coefficients not provided, only p-values | I: N = 10; II: N = 9
Lang et al. (2008) ^a^; Confidence: High | Paraformaldehyde, “quasistatic” chamber conditions, analytical concentrations reported; 0, 0.19, 0.37, 0.62, peaks to 1.23 mg/m^3^; Adequate | Self-report, questionnaire; objective measures | Random assignment to order of exposure, double blinded. | Within person comparison | Graphs/tables and statistical analyses | N = 21
Mueller et al. (2013) ^a^; Confidence: High | Paraformaldehyde, dynamic chamber, analytical concentrations reported; clean air, 0.37 + 4 peaks of 0.74 mg/m^3^, 0.49 + 4 peaks of 0.98 mg/m^3^, 0.62 mg/m^3^ and 0.86 mg/m^3^; Good | Self-report, questionnaire; objective measures | Exposure concentrations randomly presented; blinding not described. | Within person comparison | Graphs of difference between pre- and end of test values | N = 41
Sauder et al. (1986); Not informative | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0, 3.69 mg/m^3^; Good | Self-report, questionnaire; symptom scores | Nonrandom exposure assignment, blinding not described. | Within person comparison | Provided average symptom scores & statistical analyses | N = 9
Witek et al. (1986); Schachter et al. (1986a); Confidence: Medium | Paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported; Adequate | Self-report, questionnaire; symptom scores | Random assignment to order of exposure, double blinded. | Within person comparison | Provided prevalence and score | N = 15
Schachter et al. (1987); Confidence: Medium | Paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported.; 0, 2.46 mg/m^3^; Adequate | Self-report, questionnaire; symptom scores | Random assignment to order of exposure, double blinded. Participants had routine occupational formaldehyde exposure, N = 2 smokers. | Within person comparison | Provided prevalence and scores | N = 15
Schuck et al. (1966); Not informative | Propylene and ethylene photooxidation with UV light; eye exposure only; analytic concentration reported graphically; 0.12–1.23 mg/m^3^; Deficient | Self-report, questionnaire; objective measures | Nonrandom exposure assignment, blinding not described | Within person comparison | Graphs | N = 12
Witek et al. (1986); Witek et al. (1987); Confidence: Medium | Paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported; 0, 2.46 mg/m^3^; Adequate | Self-report, questionnaire; symptom scores | Random assignment to order of exposure, double blinded. | Within person comparison | Provided prevalence and score | N = 15
Yang et al. (2001); Not informative | Plywood exposure; 2.03, 3.68, 5.3 mg/m^3^; eye exposure only; Analytical concentrations reported for formaldehyde but not for other off gassed compounds; Deficient | Objective measure | Random assignment to order of exposure, double blinded. 25% smokers. | Within person comparison | Graph of eye blink frequency and table of p-values | N = 8

a At the request of EPA’s Office of Chemical Safety and Pollution Prevention, EPA’s Human Studies Review Board review of four intentional exposure studies for potential use in assessing acute formaldehyde inhalation determined the ethical conduct of this study to be adequate.

#### Anatomy Course Studies

Table B-31 Evaluation of studies examining sensory irritation in humans: anatomy courses

Reference, setting and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Akbar-Khanzadeh et al. (1994); (Ohio) Anatomy students (cross-sectional) | Medical students and instructors in anatomy lab; referents were nonmedical students and instructors. Of 54 volunteers, 5 referents dropped out and 3 smokers excluded. | TWA personal breathing zone samples obtained on all exposed subjects (9 d), and 1 unexposed (6 d).; Exposed mean 1.53, range 0.086 to 3.62 mg/m^3^.; Referent mean 0.12, range 0.09 to 0.17 mg/m^3^. | Self-report, Medical Research Council standardized questionnaire | No comparisons reported. | Provided symptom prevalence during exposure, no comparison to baseline or to unexposed; no statistical data analysis | 34 exposed; 12 referent | Not Informative; No within person comparison to baseline or the referent; Reporting deficiencies
Chia et al. (1992); (Singapore) Anatomy students (cross-sectional) | Medical students in 1^st^ year lab course (92% participation); referent group = 3^rd^ or 4^th^ year medical students (participation rate not reported) | Area samples at dissecting tables, n=6, collected on two occasions.; Personal samples, n=14 students, duration 2.5 hours; mean 0.91, SD = 0.22 mg/m^3^, range 0.50 to 1.48 mg/m^3^, LOD = 0.062 mg/m^3^. Assumed no formaldehyde exposure in referent based on activities (ward rounds and classroom). | Self-report, modified MRC standardized questionnaire; symptoms during previous 4 wks of course (recall accuracy reduced?) | Comparison to referent matched on age, sex, and ethnicity; Questions about dissimilarity of 1^st^ and 4^th^ year students | Symptom prevalence in exposed compared to referent; Referent activities very different | Exposed N = 150; referent N = 189 | Low; Questions about dissimilarity of 1^st^ and 4^th^ year students and potential for recall bias during previous 4 weeks of course. No measurements of formaldehyde among referent group.
Fleisher (1987); Anatomy students (cross-sectional) | 44% of 204 surveyed in gross anatomy course; of those less than 50% responded to both questionnaires. Possible greater motivation to participate among those with symptoms. | Area samples in 6 labs, 1 d during semester (approximately 3 hrs); Drager tubes, 3 labs, LOD 1.23 mg/m^3^, NIOSH method, 3 labs, LOD 0.02 mg/m^3^. Personal breathing zone for 2 instructors. 0.64, 0.18 mg/m^3^; probable nondifferential misclassification due to sampling method with low sensitivity (3 labs) and low frequency of sampling. Adequate differentiation between exposure groups | Self-report, questionnaire; data collection 1 mo after end of course; symptoms all or some of the time, rarely or never. (temporal gap reduced recall accuracy?) | Within person comparison: symptoms during lab with exposure compared to lab with no exposure to formaldehyde. | Compared mean symptom scores, paired t-test | N = 38 | Low; Low response to both questionnaires and selection potential; with potential for symptoms to contribute to motivation to participate. temporal gap in symptom response reduced recall accuracy potential
Kriebel et al. (1993); (Massachusetts) Anatomy students (panel) | 96% participation | Personal samples in the breathing zone, 1–1.5 hrs; multiple days. Range 0.60–1.14 mg/m^3^, geometric mean = 0.9, SD 1.5 mg/m^3^ | Self-report; questionnaire before, during and immediately after lab each day | Within person comparison: symptoms during and after lab compared to prelab symptoms. | Symptom prevalence before, during and after lab. Mean prelab and cross-lab change over 10 weeks evaluated using multivariate linear regression | N=24 | High
Kriebel et al. (2001); (Massachusetts) Anatomy students (panel) | 94.4% participation; attendance declined from n=37 to n=10 over 13 wks (better attendance by healthy individuals?) | Individual TWA using zone-exposure matrix based on continuous monitoring in 6 homogenous sampling zones (LOD = 0.06 mg/m^3^). 12 min work-zone concentrations calculated using sampling data and recorded work; locations. Mean 1.35, SD 0.69 mg/m^3^; 12 min peak 13.42 mg/m^3^ | Self-report, questionnaire; symptom intensity 10-point scale | Within person comparison: symptoms before and after lab | Generalized estimating equation regression accounting for lack of independence of repeated measures in individuals; symptom intensity, % change per ppm or ppm-weeks | N=38 | Medium; Decline in attendance over time potentially based on exposure and outcome status.
Mori et al. (2016) (Japan) Medical students, 1^st^ and 2^nd^ year | Students (2^nd^ year) enrolled in afternoon gross anatomy classes, April–July 2013, mean age 22.9 years; compared to nonexposed 1^st^ year students, mean age 21.2 years. 75% males | Area sample, 5 locations during class on same day questionnaires were completed. Mean (SD) 0.1 (0.02) ppm | Questionnaire, 16 subjective symptoms, frequency never, sometimes, or often; administered April 2013 before, May 2013 during, and January 2014, 6 months after completion of course. | Presented characteristics by exposure group; adjusted for age, sex and allergy status in regression models. | Prevalence of symptoms compared, Cochran’s Q test and McNemar’s test; Regression of presence or absense of symptoms in relation to exposure group on day of survey, controlling for doctor-diagnosed allergies, sex and age | 123 exposed (98.4%); 114 unexpose d (91.9%) | High
Saowakon et al. (2015) (Tailand) Medical students and academic staff | Students and faculty in gross anatomy dissection labs; Selection, recruitment and participation was not reported. Ages 19–21 years, nonsmokers with no history of chronic respiratory disease or symptomatic illness | Personal samplers (n=36 students, 4 instructors); area samples, all NIOSH2016 method; 3-hr samples over duration of class, 3 classes, January, August, and October Students: Mean (SD) ppm Class 1: 0.193 (0.120) Class 2: 0.271 (0.159) Class 3: 0.828 (0.182) | Questionnaire, 20 symptoms, completed before start of dissection and after chest and abdominal opening (classes 2 & 3); Severity scale, 0–4. | | Reported each symptom as percentage of score for all symptoms averaged over all classes; no comparisons | N=36 students; n=4 instructors | Not Informative; No within person comparison to baseline or the referent; reporting deficiencies
Takahashi et al. (2007); (Japan) Medical students (panel) | Selection, recruitment and participation was not reported. | Exposure measurements on day 1. Area samples in 8 locations in lab, > 10 min; Personal samples (breathing zone) on 18/143 students. Mean 3.0, SD = 0.60 mg/m^3^, range 2.2 to 4.6 mg/m^3^. | Self-report, questionnaire after 1^st^ day and at end of 2-mo course.; Questionnaire not described. Lack of temporal correspondence between exposure measurements and symptom measurements at end of course. | Within person comparison: symptoms after 1^st^ day and at end of course | Symptom prevalence after first day and after lab at end of course; McNemar exact test (estimated from Figure 1 in publication). | N = 143 | Medium; Large gap between symptom ascertainment at end of course and exposure measurements. Selection, recruitment and participation was not reported.
Takigawa et al. (2005); (Japan) Anatomy students (intervention) | Volunteers; 76% completed questionnaires both before and during lab | Area samples in 9 locations in lab, > 10 min. Personal samples on 24 of 78 in phase I (2001) (duration 42–962 minutes); median 3.3 mg/m^3^, range 2.2 to 8.9 mg/m^3^, and on 46 of 79 in phase II (2004) (duration 100–540 min); median 0.88 mg/m^3^, range 0.40 to 3.4 mg/m^3^. | Self-report, questionnaire before and during each course; frequency (4-point scale); score change during session | Groups similar in age and % male/female; prevalence of smoking not reported. | Symptom change index, 25 symptoms, by phase of intervention; Mann-Whitney test. | N = 78 | Medium; Uncertainty regarding impact of smoking on sensitivity of response to intervention
Uba et al. (1989); (California) Anatomy students (panel) | 78.6% completed both questionnaires | Personal sampling (impingers) in the breathing zone over 7 mos; multiple days; TWA concentration; range 0.06 to 1.14 mg/m^3^ | Self-report; American Thoracic Society questionnaire; symptoms after lab on one day in November (at approx. 8–10 wks); symptoms before 1^st^ day and after last day (Sept 1984–Apr 1985) | Within person comparison: persistent symptoms beginning and end of course (7 mos); also symptoms during lab session compared to lab with no exposure to formaldehyde. | Numbers with symptoms in exposed and unexposed labs; McNemar’s test paired samples, OR, p-value. | N = 81 | High
Wantke et al. (1996b); (Austria) Anatomy students (panel) | Volunteers; participation 37.5% (45 of 120 students) | Area samples; Continuous daily measurements for formaldehyde at 2 locations during 3-hr lab, 5 d/wk for 4 wks. Mean 0.15, range 0.07 to 0.27 mg/m^3^ | Self-report, standardized questionnaire at beginning (symptoms during 3 mos before lab) and at end of course (symptoms over last 4 wks). Potential for differential recall of symptoms. | Within person comparison | Symptom prevalence before and during lab; McNemar exact test; multiple measurements during course would be ideal | N = 45 | Low; Low participation, Potential for differential recall of symptoms.
Wantke et al. (2000); Austria Anatomy students (panel) | Uncertainty regarding selection and recruitment details; Study repeated in subset. 27 of the 45 students in Wantke et al. (1996b) | Area samples; Continuous daily measurements for formaldehyde and phenol at 2 locations during lab, exposures for 43 d. Mean 0.27, range 0.13 to 0.41 mg/m^3^ | Self-report, questionnaire at beginning, 5 wks and 10 wks, Daily symptom cards during class. | Within person comparison; symptoms at beginning and during lab at middle and end of 10-wk course | Symptom prevalence before, middle and at end of 10 wk course; McNemar exact test. | N = 27 | Medium; Uncertainty regarding selection and recruitment details.
Wei et al. (2007); Anatomy students (cross-sectional) | Volunteer, all students present on the day that sampling was conducted. | Area samples near dissection tables, 30 min samples, N = 12. Measurements before, beginning, middle and completion of 3-mo gross anatomy class. Geometric mean: before 0.03, beginning 0.89, middle 0.76, end 0.24 mg/m^3^ | Self-report, questionnaire on sampling days after 2 hrs of lab. Symptom questionnaire was not completed outside of class so difference may have been influenced by perception relative to symptoms in class (possibly resulting in overestimation of risk) | Within person comparison | Frequency of symptoms during class; prevalence and severity scores during class compared to “usual life situation”; Walsh test (inadequate comparison) | N = 79–94 | Not Informative; Comparison to “usual life” unreliable

#### Occupational Studies

Table B-32 Evaluations of studies examining sensory irritation in humans: occupational studies

Reference, setting and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Alexandersson et al. (1982) (prevalence) | All exposed workers employed >1 year; evaluated employees present at work on study day (both exposed and referent); Selection for healthy survivors | TWA personal sampling for formaldehyde, terpenes & dust, N= 31; 1 working d, 6–7 hrs 0.05–1.62 mg/m^3^; no measurements for referent group; Although no measurements in referent, high concentration in exposed allows assumption of an adequate exposure contrast for comparison of exposed and referent | Self-report, British Medical Research Council questionnaire; symptoms at work, same day as exposure assessment | Symptom prevalence in exposed compared to referent. Exposed: employees of carpentry works; referents were not exposed to formaldehyde or other irritants in same factory; Similar % age, height, sex, & weight. Prevalence smoking 48% in exposed, 40% in referent. | Symptom prevalence at work compared between exposed and referent, chi-square | N = 47 exposed; N = 20 referent | Medium; Potential for healthy survivor bias with attenuation in measure of association.
Alexandersson and Hedenstierna (1989) (prevalence,; [Note: follow-up of Alexandersson et al. (1982)] | Evaluated employees who participated in previous study, 4 year follow-up (Alexandersson et al., 1982); 13 exposed and 2 referents lost-to-follow-up; 13 exposed transferred to unexposed jobs possible survivor bias | TWA using personal sampling, 3–4 15 min samples/person; 2 working d; Mean 0.5 mg/m^3^; Mean peak 0.69 mg/m^3^ limited sampling period; although no measurements in referent, high concentration in exposed allows assumption of an adequate exposure contrast for comparison of exposed and referent | Self-report, British Medical Research Council questionnaire | Symptom prevalence in exposed compared to referent. Exposed: employees of carpentry works; referents were not exposed to formaldehyde or other irritants in same factory; Similar % age, height, sex, & weight. Prevalence smoking 50% in exposed, 33% in referent. Moderate concern for confounding by smoking (direction of bias unclear). | Change in symptom prevalence at work 1980–1984, chi-square | N = 21 exposed; N = 18 referent | Low; Evidence of healthy survivor bias; confounding by smoking
Alexandersson and Hedenstierna (1988); Supplemental: Alexandersson (1988) (prevalence) | Selection for healthy; evaluated employees present at work on study day (both exposed and referent) | TWA using personal sampling, 3–4 15 min samples/person; 1 working d, no concentration reported for referent 0.12–1.32 mg/m^3^ Although no measurements in referent, high concentration in exposed allows assumption of an adequate exposure contrast for comparison of exposed and referent | Self-report, standardized questionnaire; outcome assessed same day as exposure | Symptom prevalence among workers exposed to acid-hardening lacquers; referents were “nonexposed” employees at same factory. All male, exposed slightly younger, 50% smokers; referent: 33% smokers. Sampled for dust and solvents: authors considered all exposures to be very low and not confounders. Moderate concern for confounding by smoking (direction of bias unclear). | Symptom prevalence at work compared between exposed and referent, chi-square; no adjustment | N = 38 exposed; N = 18 referent | Low; Potential for healthy survivor bias with attenuation in measure of association. Confounding and no adjustment in analyses
Herbert et al. (1994) (prevalence) | Participation >90% in exposed, >80% in referent; Healthy survivor effect likely similar among exposed and referent groups | TWA continuous sample in breathing zone; 5 sites, 2 d 0.09–0.33 mg/m^3^ referent not reported; sampled for dust. Although no measurements in referent, formaldehyde exposure not expected for oil/gas field workers, adequate exposure contrast likely for comparison of exposed and referent. | Self-report, Respiratory symptoms ascertained via interview using standardized questionnaire | Possible respiratory irritants in comparison group (oil sands workers); higher prevalence of smokers (52% vs 28%) and shorter duration of employment among exposed, (5 versus 10 years) | Symptom prevalence compared by exposure group, chi-square; unadjusted analyses | N = 99 exposed; N = 165 referent | Low; Different prevalence smoking and duration of employment between exposed and referent; no adjustment in analyses
Holmström and Wilhelmsson (1988); Wilhelmsson and Holmstrom (1992) (prevalence) | 100% participation; healthy survivor bias probable; source populations for exposed and referent (government clerks) were different, raising possible unmeasured confounding | Area samples in one group, 1979–1984, personal samples (1–2 hrs) in 1985 in all groups. Sampling data in referent. 0.05–0.5 mg/m^3^ Adequate exposure contrast for comparison of exposed and referent | Self-report, questionnaire | Groups similar for age and smoking, 87% and 93% male in exposed, 56% male in referent (gender related differences in perception of irritation?) No exposure to solvents, concentrations for other chemicals all <1% of OEL (phenol, ammonia, epichlorhydrin, methanol and ethanol). | Compared symptoms prevalence across exposure groups, chi-square; unadjusted analyses | N = 70 Group 1, N = 100 Group 2; N = 36 referent | Low (↓); Potential for healthy survivor bias with attenuation in measure of association.; groups selected from different source populations; Questionnaire not described. Potential confounding and no adjustment in analyses
Holmström et al. (1991) (prevalence) | Details of recruitment and participation not described. Healthy survivor bias probable; source populations for exposed and referent were different, raising possible unmeasured confounding | Personal exposure measurements stable through year, average 0.2–0.3 mg/m^3^, peaks seldom > 0.5 mg/m^3^ Formaldehyde Concentration, mean MDF 0.26 mg/m^3^, wood dust 0.25 mg/m^3^, referent 0.09 mg/m^3^; adequate exposure contrast for comparison of exposed and referent | Self-report, questionnaire | MDF group slightly older (44.1 year) compared to wood (39.3 year) and referent (39.9 year); % male varied, smoking less prevalent in referent | Exposed groups each compared to referent; prevalence rate difference, 95% confidence intervals; no adjustment | MDF: N = 16 Wood: N = 29 Referent: N = 36 | Low (↓); Uncertainty regarding selection and recruitment details; Potential for healthy survivor bias with attenuation in measure of association.; groups selected from different source populations; Potential confounding and no adjustment in analyses
Holness and Nethercott (1989) (prevalence) | Minimal concern for selection bias. Recruitment source was list provided by funeral home association, 86.6% of eligible participated. Participation rate among referents was not given. | 2 area samples (impingers), during embalming, 30 to 180 min. Gave concentration for referent. 0.1–1.0 mg/m^3^ Adequate exposure contrast for comparison of exposed and referent | Self-report, American Thoracic Society questionnaire; before and after embalming | Symptom prevalence compared between exposed (apprentice funeral service workers) and unexposed (service volunteers and paid students), probable unmeasured confounders. Groups similar for age, height, and smoking status. Source of formaldehyde exposure was formalin (also contained methanol) | Comparisons between exposed and referent, logistic regression adjusted for # pack-years smoked. Provided data and results of statistical analyses | N = 84 exposed; N = 38 referent | Medium; Differences in source populations for exposed and referent groups lead to uncertainty in comparability, with no consideration of potential confounding.
Horvath et al. (1988) (Wisconsin) Occupational (prevalence) | 71% participation in exposed; 88% participation in referent. Age and sex distribution in participants similar to entire workforce in their respective companies. Evaluated and ruled out survivor bias using reasons for leaving employment among 54 former employees; evaluated characteristics of 30/45 nonparticipants who were younger and higher % male, with similar % smokers and mobile home residency. | 8-hr TWA using Personal and area sampling on day of exam. Exposed mean 1.04, range 0.32 to 4.48 mg/m^3^. Referent mean 0.06, range 0.04–0.15 mg/m^3^; adequate exposure contrast for comparison of exposed and referent | Self-report, American Thoracic Society questionnaire; assessed same day as exposure assessment; before and after shift | Symptom prevalence in exposed workers at a particleboard manufacturing plant compared to referent workers at 2 food production plants. Higher proportion male in exposed and slightly older average age (expect any potential bias toward null for symptoms). Smoking and mobile home residency similar. Particulate exposure in exposed and referent (different sources), other chemical exposures were not detectable or below PEL. | Symptom prevalence during work in exposed and referent compared; prevalence at end of shift using multiple regression. Uncertain whether analyses adjusted for age or gender. | N = 109 exposed; N = 254 referent | Medium; Uncertain whether analyses adjusted for age or gender, although groups were compared and differences were not large.
Kilburn et al. (1985a) (prevalence) | 76 female histology technicians in 23 hospitals & 2 labs (exposed), 97% of eligible, mean (SD) age 40.8 (11.6) years; 56 women in referent (secretaries and clerks in same institutions) matched with 40 of the technicians for age, cigarette smoking, and ethnicity, mean (SD) age 39.5 (10.5) years. | Environmental samples for formaldehyde, xylene, toluene, and chloroform by regional NIOSH laboratory in 10 of 25 labs; 1–4 hours sampling time; self-report of duration of exposure (hrs/d) 0.25–2.34 mg/m^3^; adequate exposure contrast for comparison of exposed and referent | Self-report, questionnaire, composite experience for previous months or years (reduced accuracy of recall) | Incomplete matching: Among 76 exposed, group of 40 matched to referent on age, cigarette smoking, and ethnicity; multiple chemical exposures; evaluated effects among participants with >4 hrs formaldehyde exposure/d stratified by 2 levels for xylene. | Prevalence by hours formaldehyde exposure and xylene exposure; results of statistical analyses not reported. | N = 76 exposed; N = 56 referent | Low; Extended time period for symptom reporting may have reduced accuracy of recall; incomplete matching; results of statistical analyses were not reported.
Löfstedt et al. (2011b) (prevalence) | >90 % participation in exposed and referent; healthy worker survival? Higher proportion of referents had ever had asthma or allergic symptoms in childhood | Individual samples over a single 8-hr shift 0.013–0.19 mg/m^3^, geometric mean 0.037 mg/m^3^; subjects categorized into low and high formaldehyde using LOD; also sampled MCA, ICA and dust | Self-report, questionnaire; existence of symptoms during prior week (reduced recall accuracy?) | Referent from the same industry (not workers in core production or die casting), comparable for age; smoking prevalence, prevalence female, and work duration higher in referent. Symptom prevalence compared between groups. Co-exposures measured but not adjusted for in analysis. Independent effect of formaldehyde could not be determined | Logistic regression models, symptoms by referent, low and high formaldehyde groups; no adjustment for other irritants (isocyanic acid, methyl isocyanate, dust) which were strongly associated with symptoms. Also restricted analyses excluding asthma or allergies, females, or smokers with similar results | N = 43 of 48 exposed; N = 69 of 84 referents | Low (↑); Could not distinguish effect of formaldehyde from those of other irritants that were strongly associated with symptoms; Questionnaire not described. Potential for information bias (reduced recall accuracy); higher proportion of asthma or allergy among referents raises potential healthy worker survival
Neghab et al. (2011) (prevalence) | 100% participation; healthy worker survival? | Area samples (40 minutes, N = 7) in 7 workshops and 1 in office area. Mean 0.96 mg/m^3^; SD 0.49 mg/m^3^; adequate exposure contrast for comparison of referent | Self-report, interview & American Thoracic Society questionnaire; symptoms at work prevalence (25%). | Referent from the same industry and comparable for socioeconomic status, age, smoking compared between groups. | Symptom prevalence compared by exposure group, chisquare Symptom prevalence | N = 70 exposed N = 24 referents | Medium; Potential for healthy survivor bias with attenuation in measure of association.

### B.3.3 Pulmonary Function

The details of the study evaluation approach methods are provided in Section 2.3.3 of the Toxicological Review. Within Tables B-33 (including epidemiological laboratory student studies, residential- and school-based studies, and occupational studies) and B-34 (controlled exposure studies) below documenting the results of the study evaluations for pulmonary function, studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating.

#### Epidemiology Studies

Table B-33 Evaluation of formaldehyde-pulmonary function epidemiology studies

Reference | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Laboratory Students Studies
Akbar-Khanzadeh et al. (1994) (Cross-sectional) | Medical students and instructors in anatomy lab; referents were nonmedical students and instructors. Of 54 volunteers, 5 referents dropped out and 3 smokers excluded. | TWA personal breathing zone samples obtained on all exposed subjects, 9 d, and 1 unexposed. 6 d Range 0.086–3.62 mg/m^3^ Also sampled methanol (mean 110 ppm) and phenol (not detected) | Cross-lab change using pre- and postlab spirometry using ATS criteria on 1 d per student; all had at least 6 wks of formaldehyde exposure at time of spirometry | Age (26 vs. 32 year), height and weight similar between exposed and unexposed; 21% with history of asthma in exposed and none in referent; nonsmokers | Mean (SD) absolute value at baseline and mean % difference across lab compared within and between groups; t-test | N = 34 exposed; 12 referents | Cross-lab change; Medium; Small sample size in referent. Potential confounding by history of asthma in between group analyses.
Akbar-Khanzadeh and Mlynek (1997) (Cross-sectional) | Medical students enrolled in anatomy laboratories matched by age to referent class occurring at the same time (physiotherapy students) | Personal (breathing zone) (n = 44) and area (n = 76) formaldehyde samples Range 0.34–5.47 mg/m^3^ | % predicted; prelab and postlab spirometric variables; 4 students assessed each time | Variables expressed as a percentage of reference values accounting for height, weight, age, sex, and race; all nonsmokers. Matching incomplete for males. Potential confounding by time related changes in individual response | Mean cross-lab change analyzed within and between groups using regression model and t-test | N = 50 exposed; 36 referents | Cross-lab change; Low (↓); Potential confounding by time related changes in individual response and for difference in gender composition in between group comparison.
Binawara et al. (2010) (Cross-sectional) | Excluded individuals with symptoms, stress, type-1 allergy, respiratory disease, and smokers First-year medical students in anatomy lab | No formaldehyde measurements | Pre- and postlab spirometry, % predicted, day of course not reported | Within person change | Percent predicted prelab compared to postlab means (SD), t-test; no comparison group | N = 80 | Cross-lab change; Low; No comparison group
Chia et al. (1992) (Cross-sectional) | Subjects selected randomly; all agreed to participate | Area samples at dissecting tables, n = 6, collected on two occasions. Personal samples, n = 14 students, duration 2.5 hrs Range 0.50–1.48 mg/m^3^ | Spirometric measures (published methods); once before and after dissection, 1^st^ d after 2-wk vacation. | Within person change; before and after dissection means adjusted for age and height, stratified by sex. | Means, absolute values adjusted for age and height, stratified by gender; and p-values; no SE; no comparison group | N = 22 | Cross-lab change; Low; No comparison group; Small sample size
Khaliq and Tripathi (2009) (Cross-sectional) | Participants randomly selected; excluded students with respiratory illness or previous exposure to formalin; all nonsmokers | No formaldehyde measurements. Formaldehyde exposure assumed for dissection classes | Pre- and postlab spirometry; 3 tests using best value, measured on 1^st^ day of exposure and 24 hrs after | Within person change | Mean absolute value (SD) compared pre- and postlab, t-test; no comparison group | N = 20 | Cross-lab change; Low; No comparison group; Small sample size
Kriebel et al. (2001) (panel study) | 51 gross anatomy students (out of 54 total) during a 12-wk class meeting once per week. 94% participation; attendance declined from n = 38 to n = 10 over 13 wks (better attendance by healthy individuals?) | Work-exposure matrix from sampling in 6 work zones, multiple days, and reported time spent in each zone Average 1.35 mg/m^3^, 10-min peak 13.42 mg/m^3^ | Spirometric measures (ATS methods) before and at end of 13 wks. PEF, prelab and across-lab change every weekly lab session | Within person change; multiple measurements; 2 smokers and 7 ex-smokers, PEF in smokers no different from nonsmokers | PEF as fraction of value before 1^st^ lab session analyzed longitudinally; Individual prelab and cross-lab change data analyzed together in relation to recent, average and cumulative formaldehyde in single generalized estimating equations model. GEE adjusted for cold on lab day. | N = 38 of 51 with pre- and postlab measures for ≥1 week | Longitudinal; Medium (↓); Attrition and declining concentration over course―bias to healthy individuals and toward null; Cross-lab change; Low; No comparison group
Kriebel et al. (2001) (panel study) | | Work-exposure matrix from sampling in 6 work zones, multiple days, and reported time spent in each zone Average 1.35 mg/m^3^, 10-min peak 13.42 mg/m^3^ | Spirometric measures (ATS methods) before and at end of 13 wks. PEF, prelab and across-lab change every weekly lab session | Within person change; multiple measurements; 2 smokers and 7 ex-smokers, PEF in smokers no different from nonsmokers | Cross-lab change: no comparison group. | N = 38 of 51 with pre- and postlab measures for ≥1 week | Longitudinal; Medium (↓); Attrition and declining concentration over course―bias to healthy individuals and toward null; Cross-lab change; Low; No comparison group
Kriebel et al. (1993) (panel study) | 24 clinical anatomy students (out of 25 total) during a 10-wk anatomy class meeting once a week. 96% participation | Personal samples in the breathing zone, 1–1.5 hrs of 3-hr lab; multiple days Range 0.60–1.14 mg/m^3^ Pentachlorophenol measured but not detected. | PEF repeated measures Wright flow meter; measured 1–3 times during each weekly lab | Within person change; multiple measurements; one smoker | Mean absolute value (SD) prelab (longitudinal) and cross-lab change in pulmonary function analyzed in separate models using random effects models including asthma, asthma*week, eye and nose or throat symptoms. Provided data and results of statistical analyses; Also showed absolute value (SD) and cross-lab change (SD) at weeks 1 and 2 and 9 and 10 | N = 20 in analysis out of 24 | Longitudinal; Medium; Small sample size; Cross-lab change; Low; No comparison group
Kriebel et al. (1993) (panel study) | 24 clinical anatomy students (out of 25 total) during a 10-wk anatomy class meeting once a week. 96% participation | Personal samples in the breathing zone, 1–1.5 hrs of 3-hr lab; multiple days Range 0.60–1.14 mg/m^3^ Pentachlorophenol measured but not detected. | PEF repeated measures Wright flow meter; measured 1–3 times during each weekly lab | Within person change; multiple measurements; one smoker | Cross-lab change: no comparison group | N = 20 in analysis out of 24 | Longitudinal; Medium; Small sample size; Cross-lab change; Low; No comparison group
Mohammad `pour and Maleki (2011) (cross-sectional) | 30 veterinary students, male and female, aged 18–20 year, nonsmokers; selection of participants not described | No formaldehyde measurements | Pre- and postlab spirometry | Within person change; nonsmokers, age comparable | Mean absolute value (SD) compared pre- and postlab, ANOVA; tested interaction between sexes and exposure | N = 15 females; N = 15 males | Not Informative; No comparison group, small sample size increased potential for unreliable results. Exposure levels uncertain and likely variable in this occupational group
Saowakon et al. (2015) (Thailand); Medical students and academic staff | Students and faculty in gross anatomy dissection labs; selection, recruitment, and participation were not reported. Ages 19–21 years, nonsmokers with no history of chronic respiratory disease or symptomatic illness | Personal samplers (n = 36 students, 4 instructors); area samples, all NIOSH-2016 method; 3-hr samples over duration of class, 3 classes, January, August, and October Students: Mean (SD) ppm Class 1: 0.193 (0.120) Class 2: 0.271 (0.159) Class 3: 0.828 (0.182) | Siblemed 120 protable spirometer, completed before start of dissection and after end of dissection lab, maximum of two readings | Within person change; all nonsmokers | Average change over one 3-hr lab session in the exposed group (Within person change), paired t-test. Uncertainty whether each participant was assessed more than once. No comparison to referent group | N = 36 students; N = 4 instructors | Cross-lab change; Low; No comparison group
Uba et al. (1989) (panel study) | 96 medical students (72.5% participation) during a 7 mo anatomy class meeting twice a week | Personal sampling monitors (impingers) in the breathing zone; multiple days and during 3 different months TWA Range 0.06–1.14 mg/m^3^ | Spirometric measures (ATS methods); Absolute value (SD) pre- and postlab and cross-shift change before Day 0 (before exposure), at 2 wks and 7 mos | Within person change; all nonsmokers | Cross-shift change in pulmonary function analyzed using repeated measures ANOVA, adjusted for sex; change at 2 wks and 7 mos compared to the baseline day (longitudinal). Compared mean values measured at noon on baseline day, 2 wks and 7 mos. (cross-lab change) | N = 96 | Longitudinal; High; Cross-lab change; High
Residential Studies and School-Based Studies
Bentayeb et al. (2015); (Cross-sectional), 2009–2011 | Elderly (20 randomly selected per home) permanently living in randomly selected nursing homes (8 per city) in selected city in 7 countries. Exclusion criteria stated (neurological or psychiatric disorders) | Measurements in common room, uncertainty regarding average individual exposure; 1 wk samples; also measured particulates, NO_2_, ozone, temperature, humidity and CO_2_; range of 1 wk averages 0.001–0.021 mg/m^3^, median 0.006 mg/m^3^; categorical (low and high) based on median concentration in each nursing home | Assessed by same team in all countries; medical visit and standardized questionnaire (European Community Respiratory Health Survey); spirometry (ATS/European Respiratory Society guidelines), % predicted | Adjusted for sex, age, country, BMI, highest school level, smoking, and season. Confounding by co-exposures was not assessed. | General estimating equations analysis, accounting for correlations within nursing homes; adjusted OR (95% CI); stratification by presence or ventilation. Presented risk above versus below the median formaldehyde level in each nursing home (medians were not reported). | N = 600 | Medium; Confounding by coexposures was not assessed; median concentrations which defined low and high exposure categories were not reported.
Broder et al. (1988b, 1988c); Broder et al. (1988a) (Cross-sectional) | Identification of exposed through households with UFFI registered with state consumer agency; referents selected randomly from houses on adjacent streets; concern for possible over-reporting of symptoms but not for pulmonary function | Area samples on 2 successive days in hallway, all bedrooms and yard. Median conc. in rooms were similar, Inside: referent 0.035 ppm, range 0.006–0.112 ppm [0.043 mg/m^3^, range 0.007–0.138 mg/m^3^]. 90% 0.061; UFFI 0.043 ppm, range 0.007–0.227 [0.053 mg/m^3^, range 0.009–0.279 mg/m^3^], 90% 0.073 ppm Outside: referent 0.005 ppm, UFFI 0.005 ppm. Exposure contrast between exposure groups small. | Spirometry protocol described | Adjustment for important confounders in data analysis. | Regression models of spirometry values between and within each exposure group, analysis adjusted for total hrs spent in house/wk, outside temperature, gender, age, height, smoking, and race; presented only statistically significant regression coefficients; no data shown for formaldehyde associations | N = 1,726 exposed; N = 720 referent | Within group analyses; Medium; Results not presented for formaldehyde; Between group analysis; Low; Small exposure contrast between exposure groups
Franklin et al. (2000) (Cross-sectional) | Recruitment through local schools; response rate of participants was not described. Participation not expected to be influenced by outcome or exposure | 3–4 d passive samples in bedroom and main living area Median (IQR) 0.019 (0.011, 0.035) mg/m^3^ (communication by author) | Spirometry protocol (ATS), measurements in clinic | Children with current or history of upper or lower respiratory tract disease were excluded. % predicted based on age, sex, and height. Mean eNOS levels by exposure category adjusted for age and atopic status | Mean absolute value (SD) and % predicted (SD) by exposure group (<50 and ³50 ppb); only 10 homes in high exposure group (data provided by author); no demographic info except for age | N = 224 | Medium; Limited exposure contrast; few subjects in high exposure group
Krzyzanowski et al. (1990), adults & children (cross-sectional) | A stratified random sample of 202 households of municipal employees; eligibility criteria described | Two 1-week household samples, multiple locations Mean 0.032 mg/m^3^; maximum 0.172 mg/m^3^ | PEF, Wright flow meter measured 4 times daily for 2 wks | Potential confounding analyzed in analysis | Random effects model accounting for repeated measures, adjusted for asthma, acute respiratory illness, smoking, SES, NO_2_, time of day; separate analyses for 15 years and younger, and over 15 years of age. | N = 202; repeated measures | High
Marks et al. (2010) | Schools and classrooms were selected using a 2-stage process, all students in selected classrooms (grades 4, 5, or 6) were recruited. Participation: 418 subjects (77%) of 543 students in selected classes. | One area sample in each classroom 2 d/wk for 6 wks | Spirometry protocol described | Randomized double blind intervention study of unflued and flued gas heaters, NO_2_ and formaldehyde levels varied together in same direction | Analysis of effects in relation to heater use (flued vs unflued), correlated coexposures. No formaldehydespecific analyses | N = 400 | Not Informative; No quantitative analyses specifically for formaldehyde
Norback et al. (1995) (Cross-sectional) | Recruited from 154 randomly selected members of general population; 57% participated. Possibly not representative sample because study design selected 50% subjects with asthma symptoms (may respond differently to formaldehyde exposure) | Formaldehyde (one 2-hr sample) in the bedroom at pillow height. Also measured guanine in bedroom (house dust mites), and room temperature, air humidity, VOCs, respirable dust, and CO_2_ in living room and bedroom. Limited sampling period in closed residence with no point formaldehyde emissions; sampling and analytic protocols referenced (Andersson et al., 1981) LOQ 0.1 mg/m^3^); Formaldehyde and Range <0.005–0.110 µg/m^3^ (most <LOQ) | Spirometry and peak flow protocol described; FEV_1_ (percent predicted accounting for age, sex, and height). PEF measured twice per day for 7 d; constructed variable for PEF variability (assessed in asthma section) | Analysis did not account for high prevalence of asthma symptoms in study group; VOC concentrations were correlated and effects could not be separated from those of formaldehyde (No data presented) | FEV_1_ was percent predicted accounting for age, sex, and height; Kendall’s rank correlation test | N = 88 | Low; Exposure: Most exposed to concentration <LOQ Study population selected for high prevalence of asthma symptoms; Correlated co-exposures: VOCs
Wallner et al. (2012) | 433 children (aged 6–10 years) with spirometry of 596 eligible (72.7%) in 2 classrooms each at 9 of 19 schools that volunteered to participate in study. 72.7% participation | Measurements of 252 chemicals in 9 home classrooms (exposed 6–7 hrs/d); 24 hr samples, 2 samples per classroom, 2 seasons; all students in class assigned the median chemical concentration; median 29.8 µg/m^3^ (range 6.5–136.5 µg/m^3^, all values > LOQ | Spirometry protocol described; percent of reference | Reference values based on gender, age, height, and weight of children; regression analysis controlled for SES (education and occupation of parents, urban/rural, # smokers at home. No adjustment for other chemicals in classroom. Do not expect correlation between formaldehyde and PBDE congeners or phthalates in dust | Associations with lung function analyzed for 34 chemicals; no adjustment for multiple comparisons; multiple regression model, % change per 1 SD increase in formaldehyde (value of SD not reported). | N = 433 | Medium; No adjustment for coexposures in classroom that were also associated with pulmonary function, but correlation not anticipated
Occupational Studies
Alexandersson et al. (1982) | All exposed workers employed >1 year, recruitment from workers present on study day (healthy worker effect). Referents selected from plant employees not exposed to irritants; participation rate not reported. Cross-shift change not evaluated in referent | TWA personal sampling; 1 working d. Range in exposed 0.05–1.62 mg/m^3^; referent not reported; although no measurements in referent, high concentration in exposed allows assumption of an adequate exposure contrast for comparison of exposed and referent | Spirometric measures (ATS methods); measured on Monday morning and after work in exposed; referents tested either in the morning or afternoon | Preshift variables compared to reference equations | Preshift values compared to predicted based on age, height, and gender evaluated within exposed and referent groups. SD not reported;- | N = 47 exposed; N = 20 referent | Pre-shift; Medium (↓); Concern for selection for healthy. P-values were reported; Cross-shift; Low; No comparison group
Alexandersson et al. (1982) | | | Spirometric measures (ATS methods); measured on Monday morning and after work in exposed; referents tested either in the morning or afternoon | Preshift variables compared to reference equations | Cross-shift change: compared mean values before and after shift in exposed (paired t-test) No comparison group | N = 47 exposed; N = 20 referent | Pre-shift; Medium (↓); Concern for selection for healthy. P-values were reported; Cross-shift; Low; No comparison group
Alexandersson et al. (1982); Alexandersson and Hedenstierna (1989) | Possible selection for healthy during 4-year follow-up; 13 exposed and 2 referents lost-to-follow-up; 13 exposed transferred to unexposed jobs | TWA using personal sampling among all exposed; 3–4 measurements of 15 min periods during 2 working d. Range in 1980 exposed 0.05–1.62 mg/m^3^; referent not reported; Range in 1985 not reported. Sampled for dust. Although no measurements in referent, high concentration in exposed allows assumption of an adequate exposure contrast for comparison of exposed and referent. | Spirometric measures (ATS methods); measured on Monday morning across shift in exposed; referents tested either in the morning or afternoon | Values compared to predicted normal based on age, gender, and height; analyses stratified by smoking status. Dust levels considered to be low. | Mean absolute value (SD) before work compared to predicted normal based on age, gender, and height in 1980 and 1984, and mean difference from predicted (SD) in 1984 by smoking status; 5-year change corrected for age-dependent change; stratified by smoking. Mean change across shift (SD) stratified by smoking, no comparison group (low) | N = 21 exposed; N = 18 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association; small sample; Cross-shift; Low; No comparison group
Alexandersson et al. (1982); Alexandersson and Hedenstierna (1989) | Possible selection for healthy during 4-year follow-up; 13 exposed and 2 referents lost-to-follow-up; 13 exposed transferred to unexposed jobs | | Spirometric measures (ATS methods); measured on Monday morning across shift in exposed; referents tested either in the morning or afternoon | Values compared to predicted normal based on age, gender, and height; analyses stratified by smoking status. Dust levels considered to be low. | Cross-shift change: Mean change across shift (SD) stratified by smoking, no comparison group. | N = 21 exposed; N = 18 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association; small sample; Cross-shift; Low; No comparison group
Alexandersson and Hedenstierna (1988); Alexandersson (1988) | Selection for healthy; evaluated employees present at work on study day | TWA using personal sampling, 3–4 15 min samples/person; 1 working day. Range in exposed 0.12–1.32 mg/m^3^; referent not reported; although no measurements in referent, high concentration in exposed allows assumption of an adequate exposure contrast for comparison of exposed and referent. | Spirometry on Monday after 1 d unexposed and again at end of shift on 2^nd^ day. Half of referent tested before, and half tested after shift | Referents were “nonexposed” employees at same factory. All male, exposed slightly younger, 50% smokers; referent: 33% smokers. Analyses stratified by smoking status. Sampled for dust and solvents: Authors considered all exposures to be very low and not confounders | Mean values and difference from reference values by exposure group, and by smoking status among exposed. Change over 2 d by smoking status. Mean comparisons within exposure groups, Student’s t-test | N = 38 exposed; N = 18 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association. Small sample size in referent.; Cross-shift; Low; No comparison group
Alexandersson and Hedenstierna (1988); Alexandersson (1988) | Selection for healthy; evaluated employees present at work on study day | | Spirometry on Monday after 1 d unexposed and again at end of shift on 2^nd^ day. Half of referent tested before, and half tested after shift | | Cross-shift change: No comparison group | N = 38 exposed; N = 18 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association. Small sample size in referent.; Cross-shift; Low; No comparison group
Gamble et al. (1976) | Of 68 workers exposed to hexa-methylene-tetramine-resorcinol resin, 52 (77%) completed questionnaire and lung function testing | Area samples | Spirometry protocol described | Referent matched by age, race, sex, shift, and job; Exposure to multiple chemicals | Exposure group defined by use of hexamethylene-tetramine-resorcinol resin, not formaldehyde | N = 19 exposed; N = 19 referent | Not Informative; No quantitative analyses specifically for formaldehyde
Herbert et al. (1994) | Participation 98% in exposed, 82% in referent. Excluded accidental hydrogen sulfide exposure (n = 14). | TWA continuous sample in breathing zone; 5 sites, 2 d. Range in exposed 0.09–0.33 mg/m^3^; referent not reported; sampled for dust. Although no measurements in referent, formaldehyde exposure not expected for oil/gas field workers; adequate exposure contrast likely for comparison of exposed and referent. | Spirometric measures; best of 5 maneuvers, Snowbird criteria (Ferris, 1978); at start of work shift and after 6 hrs Cross-shift change not evaluated in referent | Preshift comparisons adjusted for age, height, and smoking; not dust levels, which authors considered to be low. Potential for exposure to other irritants among referent group (oil/gas field workers) | Exposed compared to referent using ANCOVA adjusting for age, height, and cigarette pack-years. Presented absolute values and p-values from ANCOVA. Unconditional logistic regression of FEV_1_/FVC <75% controlling for age and cigarette packyears. Presented odds ratios, 95% CI by smoking category. | N = 99 exposed; N = 165 referent | Pre-shift; Medium; Potential for healthy survivor bias with attenuation in measure of association. Possible irritant exposure in referent; co-exposure to dust.; Cross-shift; Low; No comparison group
Herbert et al. (1994) | Participation 98% in exposed, 82% in referent. Excluded accidental hydrogen sulfide exposure (n = 14). | | Spirometric measures; best of 5 maneuvers, Snowbird criteria (Ferris, 1978); at start of work shift and after 6 hrs Cross-shift change not evaluated in referent | Preshift comparisons adjusted for age, height, and smoking; not dust levels, which authors considered to be low. Potential for exposure to other irritants among referent group (oil/gas field workers) | Cross-shift change: Presented absolute values of preshift and postshift with t-statistics and [underlined: p]-values; no comparison group | N = 99 exposed; N = 165 referent | Pre-shift; Medium; Potential for healthy survivor bias with attenuation in measure of association. Possible irritant exposure in referent; co-exposure to dust.; Cross-shift; Low; No comparison group
Holmström and Wilhelmsson (1988) | 70 (87% male) in formaldehyde products group (mean age 36.9 years), 100 furniture workers exposed for formaldehyde and wood dust (93% male, mean age 40.5 years), 36 persons (56% male, mean age 39.9 years) government clerks. 100% participation among those recruited Potential selection for healthy workers | Area samples in one group, 1979–1984, personal samples (1–2 hrs) in 1985 in all groups. Estimated mean formaldehyde and dust exposure of every participant for each year of employment, dose-years. Range in Group #1 0.05–0.5 mg/m^3^, Group #2 0.2–0.3 mg/m^3^; referent mean 0.09 mg/m^3^; adequate exposure contrast likely for comparison of exposed and referent. | Spirometric measures (FVC, FEV_1_/FVC) percent of expected normal based on age, sex, smoking, height, and weight. | Values compared to expected normal based on age, sex, smoking, height, and weight; respirable particulates measured but not adjusted for in analysis. Comparison groups: Formaldehyde only, formaldehyde and wood dust, referent group. Referent group was composed of administrative workers who may not be comparable to exposed. Comparable smoking status between groups (data NR) | Presented observed and expected values by exposure group, SD not reported. Statistical comparisons of observed and expected within exposure group (paired t-test); analyzed correlation with duration of exposure and cumulative dose but did not provide quantitative results | N = 70 Group 1; N = 100 Group 2; N = 36 referent | Medium (↓); Potential for healthy survivor bias with attenuation in measure of association. Comparison groups selected from different source populations
Holness and Nethercott (1989) | Participants recruited from list of funeral homes, 86.6% participation; 79.8% of embalmers were active embalmers (healthy workers); community referent less similar? | 2 area samples (impingers), during embalming, 30 to 180 min. Range in exposed 0.10–1.0 mg/m^3^, referent mean 0.025 mg/m^3^; adequate exposure contrast likely for comparison of exposed and referent. | Lung function as percent predicted; measured at initial assessment and before and after embalming procedure among exposed and before, and after a 2–3 hr period in referents. | Analyses adjusted for age, height, and pack-years smoked Differences in source populations for exposed and referent groups lead to uncertainty in comparability, with no consideration of potential confounding. | Mean percent predicted (SD) presented by exposure group or by active or inactive embalmers, p-value from regression model adjusted for age, height, and pack-years smoked; percent change during embalming | N = 84 exposed; N = 38 referent | Medium; Differences in source populations for exposed and referent groups lead to uncertainty in comparability, with no consideration of potential confounding.
Horvath et al. (1988) | 71% participation in exposed; 88% participation in referent. Age and sex distribution in participants similar to entire workforce in their respective companies. Evaluated and ruled out survivor bias using reasons for leaving employment among 54 former employees; evaluated characteristics of 30/45 nonparticipants who were younger and higher % male, with similar % smokers and mobile home residency. | 8-hr TWA using personal and area sampling on day of exam. Range in exposed 0.32 to 4.48 mg/m^3^; referent 0.037–0.15 mg/m^3^; adequate exposure contrast likely for comparison of exposed and referent. | Spirometric measures (ATS methods); % predicted | Adjusted for age, sex, height, and smoking in analyses; particulates measured but not adjusted for in analysis. Smoking prevalence 53% in both groups; mean total particulates somewhat higher in referent. Other co-exposures not detected or a fraction of PEL (respirable particulates, phenol, CO, sodium hydroxide, NO_2_ and acrolein). | Variables evaluated as percent of predicted normal; mean % predicted (SD) compared between exposure groups, t-test; multiple regression on log concentration adjusted for age, sex, height, and smoking; for cross-shift change, paired t-test (before and after) of percent predicted values | N = 109 exposed; N = 254 referent | Pre-shift; High; Cross-shift; High
Imbus and Tochilin (1988) | 76% and 84.5% of employees tested at each plant | Area samples of formaldehyde and wood dust on same day as pulmonary testing. Sampling protocol (# samples and sampling period) not described. Range in exposed <0.012–0.074 mg/m^3^ | Spirometry protocol described (ATS); cross-shift change | Within person change; values presented as percent predicted; descriptive data on study group were not given. No unexposed referent group. | Provided data, no statistical analyses presented | Plant A N = 94; Plant B N = 82 | Not Informative; Reporting deficiencies
Khamgaonkar and Fulare (1991) | Lab workers in college anatomy and histopathology departments; selected every 2nd person from occupational list. | Multiple 30min area samples in the breathing zone in exposed (N = 43) and unexposed (N = 18) areas. Range in exposed 0.044–2.79 mg/m^3^; referent mean 0.125 mg/m^3^, range ND–0.64 mg/m^3^; adequate exposure contrast likely for comparison of exposed and referent. | Spirometry protocol not described; measured on Monday. Selected every second person on list from each exposure group. | Comparison group matched by age and sex (N = 74). Comparable for mean height and weight; smoking prevalence: 54% exposed, 59% referent. Other exposures in lab | Mean absolute values (SD not reported) compared between exposed and referent; p-values reported | N = 37 exposed; N = 37 matched referent | Medium (↓); Possible exposures in referent that affect pulmonary function; exposure to formaldehyde in referent labs
Kilburn et al. (1985b) | Concern for selection bias toward overestimating association. 41% participation, volunteers, nonrandom selection of participants in exposed. | No formaldehyde concentration measurements. | Spirometry protocol described; testing before and after work shift | Potential noncomparability of batt makers and administrative employees, calculated % predicted using reference population. Possible exposure to other contaminants among batt makers | Preshift absolute values and percent predicted, and postshift absolute values by smoking status (SD not reported) among batt makers and referent group | N = 44 exposed; N = 26 referent | Not Informative; Low participation and nonrandom selection of exposed; no formaldehyde measurements and possible co-exposures
Kilburn et al. (1989a) | Attendees at 4 national conventions in 4 different cities between 1982 and 1986, compared to lung function in a Michigan population. Participation <40%; not clearly presented | Formaldehyde sampling in 10 labs in Los Angeles (not representative of entire sample); very wide range of concentration | Spirometry protocol described (ATS); percent of “referent” value | Questionable comparability to Michigan referent population; exposure both to formaldehyde and solvents; probable confounding by local air pollution in Anaheim, CA | Exposure group defined by histology technician; not specific to formaldehyde | N = 280 | Not Informative; No quantitative analyses specifically for formaldehyde
Levine et al. (1984c) | 94% participation among morticians attending a required postgraduate course | No sampling measurements; Rank order using reported # embalmings. Comparison to funeral home records for 5 persons indicated # embalmings was overreported. | Spirometric measures (ATS methods), % predicted | % predicted based on age and height; all males and Caucasian | Regression model of lung function in relation to exposure rank, adjusted for age, height, pack-years. Table 6 in the paper: mean % predicted (SD) comparing low and high rank category by smoking status, low and high rank matched by age, Student’s t-test | N = 90 | Medium; Uncertainty regarding assignment to exposure rank
Löfstedt et al. (2009) | 86% participation in exposed and 69% participation in referent. Healthy survivor effect | Personal samples on all exposed participants over a single 8-hr shift on same day as lung function testing. Range in exposed 0.014–1.6 mg/m^3^; referent not reported; major exposure was to isocyanates, low correlation with formaldehyde concentrations | Spirometry protocol described (ATS methods), cross-shift change, percent predicted using Swedish reference; testing on day after 2 unexposed days | Referent from the same industry; older age and smoking prevalence higher in exposed. Important confounders addressed in analysis. | Regression models of association of change over shift with log formaldehyde level among exposed, adjusted for smoking on test day and coexposure to ICA or MIC (in 2 models); compared mean change in % predicted across shift between exposed and referent | N = 64 exposed; N = 134 referent | Cross-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association.
Löfstedt et al. (2011a) (follow-up of Lofstedt (2009) | 90% participation in exposed and referent. Evidence of survivor bias: prevalence of childhood allergy lower among exposed in 2005 (4% versus 31%). Higher prevalence of nasal symptoms among referents in 2005. | Personal samples on all exposed participants over a single 8-hr shift on same day as lung function testing. Range in exposed in 2001: 0.014–0.44 mg/m^3^, range in exposed in 2005: 0.01–0.19 mg/m^3^; referent not reported | Spirometry protocol described (ATS methods), cross-shift change, percent predicted using Swedish reference; testing on day after 2 unexposed d | Referent from the same industry; comparable for age; smoking prevalence and work duration higher in referent. Exposure to formaldehyde, methyl isocyanate (MIC) and isocyanic acid (ICA) among exposed; correlation between formaldehyde and isocyanates low. Analysis within each exposure group | Compared preshift percent predicted values (SD) from 2001 and 2005 and change between the years (SD) within exposed and referent (Student’s t-test). Multiple regression of changes in percent predicted across shift adjusted for MIC, formaldehyde, smoking (pack-years), and childhood allergy; authors stated no significant association but quantitative results were not reported. | N = 25 exposed; N = 55 referent | Pre-shift 2001 to 2005; Low; Limited sample size to detect small changes between 2001 and 2005; concern for survivor bias; Co-exposure to MIC & ICA in exposed—unable to differentiate for comparisons of change from 2001 to 2005.; Cross-shift; Medium (↓)
Main and Hogan (1983) | All administrative personnel (exposed) and all workers on payroll (police personnel) who did not work in trailers (referent) who were still employed at end of 34–mo period. | Three 1-hour area samples (impingers), 4 occasions (August, September, December, April) always on a Monday. Range in exposed 0.15–1.97 mg/m^3^; limited sampling period in closed structure with no point formaldehyde emissions; sampling and analytic protocols referenced; referent not reported | Spirometric measures (ATS methods); Percent predicted | Percent predicted, stratified by smoking status; potential dissimilarity between administrative employees and police officers; ETS more common among referent | Percent predicted by exposure group and smoking status; t statistic and p-value presented | N = 14 exposed; N = 17 referent | Pre-shift; Low; Comparison groups selected from different sources (possible unmeasured confounding), ETS in referent; small sample size (low sensitivity)
Malaka and Kodama (1990) | Male employees at plywood company. Exposed workers randomly selected with stratification by smoking status and work duration (<5 and ≥5 years; 93% participation), mean age 26.6 years; Unexposed group matched for age, ethnicity, and smoking status (53%), worked in areas where formaldehyde was not used, and had no previous or current exposure to formaldehyde based on occupational histories; 93% participation rate. Current workers. Healthy survivor effect | Personal and area sampling, duration not reported; JEM (cumulative measure); range in exposed 0.27–4.28 mg/m^3^, referent 0.004–0.09 mg/m^3^; sampled for dust; adequate exposure contrast likely for comparison of exposed and referent. | Spirometric measures (ATS methods); % predicted and absolute values tested on Monday and cross-shift | Referent from same company; matched on age, ethnicity and smoking; analyses adjusted for age, height, weight, cigarettes per day, and dust. | Percent predicted by category of cumulative exposure (none, low, high) using ANCOVA; Linear regression of absolute value on cumulative exposure adjusted for age, height, weight, cigarettes/day, and dust. Cross-shift change: means of absolute values compared before and afer shift in exposed and referent, paired t-test | N = 93 exposed; N = 93 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association.; Cross-shift; Medium (↓)
Milton et al. (1996) | Evidence of selection of healthy workers (some refusals to avoid working in basement area); direction toward underestimation of effect | Personal sampling on each participant during 5–6 d of PEF measurement, 4 hrs on 2 d, same day as lung function testing; calculated 8-hr TWA. Range in exposed 0.0012–0.265 mg/m^3^ | Spirometry protocol described (ATS criteria); tested before and after work after 2 d off work and 2 other work d. PEF using mini-Wright peak flow meter, measurements 5 per d during and off work, 6 d at work and 4 d off. Self-reported PEF correlated with spirometric PEF (88 person-days before (r = 0.91) and after (r = 0.93) shift | Within person change, cross-over design, also adjusted for night shift and PEF at home, multiple exposures including to endotoxin, phenol resin, and formaldehyde. Concentrations were correlated—difficult to differentiate individual risk | PEF variability (high minus low for the day as percent of mean over all days). Linear regression of FEV_1_ and FVC and home amplitude percent mean PEF adjusted for smoking, pack-years of cigarettes, and years since start of exposure. Cross-shift PEF and overnight PEF, logistic regression of ≥5% decline in PEF or linear regression of change in PEF on natural log of formaldehyde; models were GEE to account for repeated measures | N = 37 | Not Informative; Potential for confounding prevents differentiation of effect of formaldehyde from effect of other exposure(s). Potential for healthy survivor bias with attenuation in measure of association.
Neghab et al. (2011) | Participation 100%. Healthy survivor effect | Area samples (40 min, N = 7) in 7 workshops and 1 area sample in office area. Range not reported, mean (SD) 0.96 (0.49); Sampling results for referent not reported; adequate exposure contrast likely for comparison of exposed and referent. | Spirometric measures (ATS methods); testing before and at end of shift on first working day of the week; percent predicted | Referent from the same industry and comparable socioeconomic and demographic status; % predicted based on age and height; all male | Pre-shift values (percent predicted) (SD) compared between exposed and referent (Student’s t-test) Regression models of lung function and association with duration of exposure adjusted for age, height, weight, and smoking. | N = 70 exposed; N = 24 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association.; Cross-shift; Low; No comparison group
Neghab et al. (2011) | Participation 100%. Healthy survivor effect | | Spirometric measures (ATS methods); testing before and at end of shift on first working day of the week; percent predicted | Referent from the same industry and comparable socioeconomic and demographic status; % predicted based on age and height; all male | Cross-shift: Pre-and postshift percent predicted compared (paired t-test), Not compared to referent. | N = 70 exposed; N = 24 referent | Pre-shift; Medium (↓); Potential for healthy survivor bias with attenuation in measure of association.; Cross-shift; Low; No comparison group
Nunn et al. (1990) | Follow-up complete (1980–1985) for 76% of exposed and 74% of referent. Attempted to include former employees; evidence of survivor bias | Area samples (1–6 hrs) 1979–1985, personal samples for representative set of exposed workers, 1985–1987, estimated prior to 1979. Range in exposed 0.1–2.46 mg/m^3^ and above. Uncertainty regarding formaldehyde levels in referent not reported | FEV_1_ values (FEV_1_/height^3^), adjusted for height | Referent group from same factory but exposed to other potential irritants (phenolic and epoxy resins, carbon fibers) and phenol- and urea-formaldehyde. Stratified results by smoking | Regression of FEV_1_/height^3^ on time of screening visit for each worker, adjusting for age in 1980, smoking status in 1980 and 1985, maximum and mean exposure rank, and total duration of exposure. Presented mean slope (95% CI) by exposure (exposed and referent), and smoking status. | N = 125 exposed; N = 95 referent | Medium (↓); Concern for selection bias: loss to follow-up higher among exposed with low lung function compared to referent; referent exposed to other potential irritants.
Ostojić et al. (2006) | 16 physicians and lab technicians exposed daily in pathology/anatomy lab (employed >4 years), source of referent not described (all male, matched for age and height) | Assessment of formaldehyde exposure was not described. No concentration data reported; exposed defined by work in pathology/anatomy lab | Spirometry protocol described; morning measurements; percent expected | Referent matched by age and stature, all nonsmokers | Compared percent predicted (mean, SD) in exposed and referent using Student’s t-test | N = 16 exposed; N = 16 referent | Not Informative; Formaldehyde measurement protocols and data not reported. Selection and description of referent group not described. Small sample size.
Pourmahabadi an et al. (2006) | Selection and participation of study groups not described. | Area samples, 8 hr average, not measured in referent | Spirometry protocol not described | Differences by group for age, length of service, height, sex, education, and smoking; no adjustment for age, height, sex, weight, or smoking | Absolute values preshift and postshift (mean, SD), and mean difference across shift (SD) compared between exposed and referent using t-test. No adjustment for age, height, sex, weight, or smoking | N = 124 exposed; N = 56 referent | Not Informative; Selection and participation of study groups not described. Reporting deficiencies in descriptions of data collection; concern for confounding.
Schoenberg and Mitchell (1975) | Participation 94%; current workers. Healthy survival effect | Formaldehyde measurements taken by insurance company during same month; 0.5–1 mg/m^3^; 3 breathing zone samples, 10.6–16.3 mg/m^3^; exposed categorized by duration; additional exposure to phenol (5–10 mg/m^3^; OSHA PEL 19 mg/m^3^). Concentrations for “never on line” not reported; adequate exposure contrast likely for comparison of exposed and referent. | Spirometric measures; measured before and after shift on Monday and Friday. | % predicted based on age, height, and gender; standardized for 15 pack-years cigarette smoking; multiple exposures (phenol) | Compared % predicted (adjusted for cigarette smoking) across categories of duration | N = 48 exposed; N = 15 referent | Medium (↓); Potential for healthy survivor bias with attenuation in measure of association. Multiple exposures: formaldehyde, phenol. Phenol is an irritant but may not be associated with pulmonary function at these levels. Small sample size in comparison groups.
Sripaiboonkij et al. (2009) | 100% and 71% participation in exposed and referent | Area samples; #, dates and protocol not described | Spirometry protocol described | Models adjusted for age, sex, education, smoking, and ETS. Co-exposures to other irritants (glass microfibers) and sensitizers (phenol resin, mineral oils) | Exposure group defined by glass microfibers or sensitizing agents; not specific to formaldehyde | N = 19 exposed; N = 159 referent | Not Informative; Exposure group defined by glass microfibers or sensitizing agents; not specific to formaldehyde; small sample size in exposed.
Tanveer et al. (1995) | 49 male workers exposed to formaldehyde resins (mean duration 15.6 year) and 29 male referents (security and administrative staff). Recruitment and participation not described. Healthy survivor effect possible | 8-hr TWA 0.03 mg/m^3^; exposure protocols and measurements not described. (concerned that TWA value may be a typo because of comment in discussion stated that findings by Dally et al. at 0.33–1.7 ppm supported by this study at 0.03 mg/m^3^) | Respiratory questionnaire, standardized MRC, and spirometry (ATS protocol); baseline in morning and at end of workshift (cross-shift measured in 31 exposed and 22 referent) | Exposed and referent comparable for age, height, smoking, and alcohol; co-exposures not discussed | Compared preshift % predicted, exposed and referent, means, by smoking status and duration of exposure, Student’s t-test; compared cross-shift change | N = 49 exposed; N = 29 referent | Not Informative Unable to assess exposure assessment or recruitment and selection protocol.

#### Controlled Exposure Studies in Humans

In addition to including shading (as described above for epidemiology studies), the controlled exposure studies in humans include italicized aspects of the study design or analysis highlight less significant limitations that had a minor impact on confidence classifications.

Table B-34 Evaluation of formaldehyde - pulmonary function controlled human exposure studies

Reference and Confidence | Exposure assessment (details on exposure quality evaluation in Appendix B.3.1) | Outcome classification | Consideration of possible bias (randomized exposure order, blinding to exposure) | Consideration of likely confounding | Results presentation | Size
Andersen (1979); Andersen and Molhave (1983); Confidence: Low | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0.24, 0.4, 0.81, 1.61 mg/m^3^ Adequate | Spirometric measures, methods not described | Random assignment to order of exposure, blinding not described. 31.2% smokers. | Within person comparison | Difference between baseline and exposure periods; ANOVA | N = 16
Day et al. (1984); Confidence: Low | UFFI off gas products, dynamic chamber, analytical concentrations reported Good | Spirometric measures; method described | Nonrandom exposure assignment, blinding not described. | Within person comparison; between group difference | Change between before and after exposure, paired t-test. Difference between groups, Wilcoxon rank sums | I: N = 9; II: N = 9
Green et al. (1987); Confidence: Medium | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0, 3.69 mg/m^3^ Good | Spirometric measures; methods and ATS criteria cited | Random assignment to order of exposure, single blinded. | Within person comparison | Ratio of exposed value at time(n) to time(0) to ratio of clean air value at time(n) to time(0); t-test | N = 22
Green et al. (1989); Confidence: Medium | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0, 3.69 mg/m^3^ Good | Spirometric measures; methods and ATS criteria cited | Random assignment to order of exposure, double blinded. | Within person comparison | Ratio of exposed value at time(n) to time(0) to ratio of clean air value at time(n) to time(0); twoway ANOVA for repeated measures | N = 24
Kulle et al. (1987); Confidence: Low | Paraformaldehyde, dynamic chamber, analytical concentrations reported; I: 0, 0.62, 1.23, 2.46, II: 0, 1.23, 3.69 mg/m^3^ Good | Spirometric measures; methods and ATS criteria cited | Random assignment to order of exposure, blinding not described. | Within person comparison | Ratio of exposed value at time(n) to time(0) to ratio of clean air value at time(n) to time(0); ANOVA | I: N=10; II: N=9
Lang et al. (2008); Confidence: Low | Paraformaldehyde, “quasistatic” chamber conditions, analytical concentrations reported; 0, 0.19, 0.37, 0.62, peaks to 1.23 mg/m^3^ Adequate | Spirometric measures; method described | Random assignment to order of exposure, double blinded. | Within person comparison | Difference before and after exposure on day 10, Wilcoxon ranked sum test; Data and results of analysis were not reported. | N = 21
Sauder et al. (1986); Confidence: Low | Paraformaldehyde, dynamic chamber, analytical concentrations reported; 0, 3.69 mg/m^3^ Good | Spirometric measures; methods and ATS criteria cited | Nonrandom exposure assignment, blinding not described. | Within person comparison | Ratio of exposed value at time(n) to time (0) to ratio of clean air value at time(n) to time(0); ANOVA | N = 9
Witek et al. (1986); Schachter et al. (1986a); Confidence: Medium | Paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported Adequate | Expressed as % of predicted (mean, SD); method citation provided. | Random assignment to order of exposure, double blinded. | Within person comparison | Percent change from baseline; t-test | N = 15
Schachter et al. (1987); Confidence: Medium | Paraformaldehyde over boiling 2-propanol, dynamic chamber, analytical concentrations reported.; 0, 2.46 mg/m^3^ Adequate | Expressed as % of predicted (mean, SD); method citation provided. | Random assignment to order of exposure, double blinded. Participants had routine occupational formaldehyde exposure, N = 2 smokers. | Within person comparison | Percent change from baseline; t-test | N = 15

### B.3.4 Immune-Mediated Conditions Including Allergies and Asthma

Details of the study evaluation approach methods are provided in Section 2.3.4 of the Toxicological Review. As discussed in that section, these reviews focused on human epidemiology and controlled human exposure studies, with animal hypersensitivity studies informing MOA (see Appendix B.3.6). Within the separate tables documenting the results of the study evaluations for observational epidemiology studies of allergies and asthma (see Table B-35), epidemiology studies of lower respiratory symptoms in infants and young children (see Table B-36), and controlled exposure studies in persons with asthma (see Table B-37), studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating. EPA consulted with two groups of experts regarding issues pertaining to ascertainment of allergy sensitization and allergies in epidemiology studies and of asthma (see Section 2.3.4 of the Toxicological review).

#### Epidemiology Studies of Allergies and Asthma

Table B-35 Evaluation of allergy and asthma studies

Reference, setting, and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Annesi - Maesano et al. (2012); (France) Schools: children (prevalence survey) | Schools randomly selected from defined geographic area, ages 9–10 years. Participation rate 81% in initial survey, 69% with full protocol. | 5-d samples in classrooms; sampling from 108 schools; all classes of specified grade level per school. Median (75th percentile) 0.027 (0.034) Maximum 0.055 mg/m^3^ (estimated from figure). Tertiles (mg/m^3^) Low <= 0.019 Medium > 9.1 - <=28.4 High > 28.4 Protocol discussed. | ISAAC questionnaire Allergy: “sneezing and runny nose accompanied by itchy eyes out of cold in the past year” Asthma: asthma in past year (wheezing or whistling in the chest or wheezing or whistling in the chest at night-time or taken asthma treatment in the past year) Exercise induced asthma based on response to pulmonary function testing after exercise protocol. Exposure measurement blinded to outcome classification | Adjusted for age, gender, passive smoking, and paternal or maternal history of asthma and allergic diseases. Also examined dampness, gas appliances, ethnicity, socioeconomic status, and season. Other measures included: NO_x_, PM_2.5_, acetaldehyde, acrolein. No other pollutants associated with rhinoconjunctivitis. PM_2.5_ and acrolein were associated with asthma. | Generalized estimating equation modeling, accounting for nonindependence of observations within-area (schools) environment, including climate. OR (95% CI) (CI estimated from figure). Models took into account within city correlations among participants. Additional stratification of asthma analysis by atopy status. Sensitivity analysis: exercise induced asthma limited to measures in same week (n = 4,643) | N = 6,683 | Allergy (rhinoconjunctivitis) and Asthma; High
Billionnet et al. (2011); (France) Residences: adults (prevalence study) October 2003–December 2005 | Nationally representative sample of residences (Indoor Air Quality Observatory study); 13.6% participation rate (567 of 4,165 households). Low participation rate; no analysis of non-participants. Age range 15-89; median 44 years. | 1-wk sample in bedroom; Median, 75th percentile (minimum, maximum) 0.0194, 0.028 (0.013, 0.0863) mg/m^3^. None < LOD. Protocol discussed. | ISAAC questionnaire: Rhinitis based on self-report of, in the past 12 mos, sneezing, running or blocked nose without cold or respiratory infection. ECRHS: Asthma based on one of following criteria: (i) having an asthma attack in the last 12 mos; (ii) having been woken by an attack of shortness of breath in the last 12 mos; and (iii) currently using asthma medicine. Exposure measurement blinded to outcome classification | Covariates chosen if associated with asthma or rhinitis and affecting one or more effect estimates for volatile organic compound exposure measures by 20% or more. Acrolein was not associated with asthma (OR 0.83). Adjusted for age, gender, smoking, education, relative humidity, time of survey, pets, mold, outdoor pollution sources within 500 meters. Did not specifically address correlation between formaldehyde and other exposures (other than noting that these were not among the higher correlations seen). | Generalized estimating equation modeling, accounting for nonindependence of within-area (dwellings) observations. OR (95% CI) (estimated from figure). Additional models took into account within dwelling correlations among participants. Compared nonparticipants (pollutant measures but no health questionnaire) and participants. Sensitivity analysis excluding relatives. | N = 1,012 38.3% rhinitis 8.6% asthma | Allergy (rhinitis) and asthma; Medium; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain.
Branco et al. (2020a); (Portugul) School: children (prevalence study) 2013–2016 | A total of 1,530 preschoolers (n = 648 3–5 years) and primary school children (n=882 6–10 years) were randomly recruited from urban and rural nursery (n = 17) and primary schools (n = 8) participating in the INAIRCHILD project. There were 2 phases in 2013/2014 and 2015/2016. Children <3 years were excluded. Participants represented 39% of the original sample. No comparisons of participants and nonparticipants. 42% were aged 3–5 years but no information on the proportion that was 3–4 years. with less specific asthma diagnosis. PFT was only conducted in the 49% who reported wheezing or asthma diagnosis Missing PFT data for 269 of 763 selected (35%). | Daily exposure based on time-averaged air concentration and reported time in specific school locations. Continuous monitoring in each room (24 hr to 9 d) (Branco et al., 2019). Time-activity obtained from parents’ 24-hr daily diary, class timetables and teachers. Inhaled daily dose estimated using time-averaged exposure, inhalation rate for each activity and body weight. Mean HCHO concentration (SD) 35.3 (43.1) µg/m^3^); 25^th^ percentile, Median, 75^th^ percentile: 0.0017, 0.0225, 0.0646 mg/m^3^ Table in article also stated that these values were the median (IQR), but clarified with the author that the values are mean and SD; author also provided data for 25^th^ and 75th percentiles (email correspondence to Dr. Glinda Cooper) (Branco et al., 2020b) | The ISAAC questionnaire was completed by parents or guardians, which were validated by physicians. Spirometry measurements were taken in participants identified as asthmatic from the questionnaire responses or reporting ever having one or more asthmatic symptoms (wheezing, dyspnea, or nocturnal cough with no upper respiratory infection) (of 763, missing or failed in 269). Spirometry before and after bronchodilator using ERS/ATS and Global Initiative for Asthma guidelines conducted by pediatric doctors with pulmonary specialization. Methods and QA described. Asthma diagnosed based on symptoms (≥ 1) and PFT results using GINA guidelines. Skin prick tests conducted on children with PFT results using several aeroallergens (n = 341, missing or failed for 153). Outcomes: reported active wheezing in last 12 mos (relevant to pre-schoolers) or reported asthma (does child have or ever had asthma?), followed by asthma diagnosis based on study physicians, FEV1/FVC <0.90, reduced FEV1 (<80% predicted), asthma diagnosed in 5.5%, asthma with or without aeroallergen sensitization, and no asthma. | Potential confounders selected based on previous experience and included site (urban, rural), study phase, sex, age group, BMI and parental history of asthma. Also controlled for surrogates of home indoor exposure including mother’s education, living with smoker. Other covariates for contact with farm animals during 1^st^ year of life, pets at home in previous year &/or 1^st^ year of | Multivariate logistic regression for each individual pollutant as continuous variable (per IQR) or dichotomized using median, or regulatory cutoffs. Models also for all pollutants simultaneously. | N = 1,530 | Asthma diagnosis; Dichotomized analysis:; Medium; Low participation rate, but potential for differential participation (by formaldehyde exposure and disease status) uncertain.; Continuous variable analysis :; Low; For continuous variable analysis: Uncertainty regarding interpretation of analysis as a continuous variable because of bimodal distribution.
Choi et al. (2009); (Korea) Residences: children (and adults?) (case-control study) March–June 2006 | Conducted in university outpatient clinic; recruitment procedure for cases or controls not described. Mean age cases 15.4 years (SD = 3.4; controls 16.2 years (SD = 4.1) | Household sample in living room at location away from sources of VOCs (sampling period not reported, but closed windows, no smoking or use of potential sources, and use of duplicates). Geometric mean 0.043 mg/m^3^, 75^th^ percentile 0.115 mg/m^3^ in controls % above LOD: 92.3 controls 94.4 atopic dermatitis cases 100 asthma cases | Atopic dermatitis and allergic asthma: based on medical history, skin prick test and IgE (criteria not provided) | No information on socioeconomic status; higher percentage of cases lived near roads or in industrial area (21%, 34%, 44% of controls, dermatitis, and asthma cases, respectively). Housing age <3 years old in 29%, 40%, and 58% in controls, dermatitis, and asthma cases, respectively; and 50%, 56%, and 72% of controls, dermatitis cases and asthma cases lived in apartments. | Nonparametric (Mann-Whitney) comparison of formaldehyde by group; geometric mean, 25^th^, and 75^th^ percentiles reported. | N = 50 atopic dermatitis cases, 36 asthma cases, 28 controls | Allergy (atopic dermatitis) and asthma; Low; Selection and recruitment process not reported; sampling period not reported and specific criteria for case definition not reported; potential confounders (age and type of housing and location differed between cases and controls, as measure of socioeconomic status) not addressed. Limited analysis.
Dannemiller et al. (2013); (United States) Residences: children (asthma control) July 2008–February 2010 | Low-income homes in Boston, recruited from past allergy cohorts, asthma clinics, newspaper ads, and referrals from other participants. (Boston Allergen Sampling Study). 79% (37 out of 47) participated in this analysis. Mean age 10.5 years. Boston Allergen Sampling Study.; Related reference on sampling: Sandel et al. (2014) | 30-minute pumped air sample in kitchen. Median 0.044 mg/m^3^; 31% >0.060 mg/m^3^; maximum = 0.162 mg/m^3^. None < LOD. Protocol discussed; analysis of sources of exposure | Asthma control (5 questions) [based on validated questionnaire]; symptoms and inhaler use in past 4 wks | Examined season, temperature, and relative humidity as well as other potential confounders (email from Karen Dannemiller to Glinda Cooper, May 6, 2015) | Log_10_-transformed formaldehyde; t-tests. | N = 37 asthma cases (out of 47 children in study, 79%) | Asthma control; Medium; Recruitment was not from a well-defined population. Limited exposure measurement period (but quality control details provided and none were < LOD).
Fransman et al. (2003); (New Zealand) Wood workers (prevalence study) | Plywood mill workers, participation rate 66%. Internal comparison by exposure level. Mean duration 4.7 years in mill, 2.7 years in current job. Workers’ knowledge of formaldehyde exposure not discussed. | Personal samples (n = 22, 15-min samples); above 0.100 (geometric mean 0.260 mg/m^3^). Limit of detection 0.030 mg/m3. | Allergy symptoms: self-report of sensitivity to house dust, food, animals or grasses/plants. | Allergy and asthma analysis: Adjusted for age, gender, ethnicity, and smoking for comparisons between high and low exposure within workplace. Weaker association seen with terpenes. Inhalable dust, abietic acid, and endotoxin also measured but not clear if these were considered in the analysis of the allergy symptoms data | Logistic regression, OR (95% CI) | N = 112 | Allergy (allergy symptoms); Low; Uncertain impact of outcome classification (inclusion of food allergies) and uncertainty regarding details of analysis; see asthma discussion for other limitations; Asthma; Medium (↓); Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. “Low” exposure group exposed to levels of formaldehyde up to 0.080 mg/m^3^. Either limitation could result in reduced (attenuated) effect estimate.
Fransman et al. (2003); (New Zealand) Wood workers (prevalence study) | | Personal samples (n = 22, 15-min samples); above 0.100 (geometric mean 0.260 mg/m^3^). Limit of detection 0.030 mg/m3. | Asthma: Current asthma medication use; past 12 mos, asthma attack or being woken by shortness of breath | Weaker association seen with terpenes. Inhalable dust, abietic acid, and endotoxin also measured but not clear if these were considered in the analysis of the allergy symptoms data | Logistic regression, OR (95% CI) | N = 112
Garrett et al. (1999a, 1999b); (Australia) Residences: children (prevalence study) | Combined analysis of cases and controls from a case-control study of asthma in 2 rural towns. Recruitment through schools and medical centers; additional advertisement for nonasthmatic children. 30 of the 95 controls were from same households as cases; the 65 other controls were from 37 households. Ages 7–14 years. | 4-day household samples (4 seasons), multiple locations; up to 0.139 mg/m^3^. Protocol discussed. Separate paper about exposure measures. 74% of children had lived in same house for at least 5 years. | Allergy and asthma: Exposure measurement blinded to outcome classification. Allergy: 12 allergen skin prick test (cat, dog, grass mix #7, Bermuda grass, house dust, 2 dust mite, 5 fungi). | Adjusted for parental asthma history, sex; other factors examined but not needed in final model (passive smoke, pets, indoor NO_2_, fungal spores, house dust mite allergens) | Prevalence (n, %) by exposure group; logistic regression, OR (95% CI); figure showing wheal size and number of positive responses by exposure group. Evaluated relation between formaldehyde and NO_x_, house dust, fungal spores, housing age. | N = 145 in allergy analysis; 53 cases, and 95 controls in asthma case-control analysis | Allergy (skin prick tests); Medium (↓); Uncertainty about effect of recruitment process and ability to fully address household correlation of cases and controls; could result in attenuated effect estimate.; Asthma; Low; Uncertainty about effect of recruitment process and ability to fully address household correlation of cases and controls; could result in attenuated effect estimate. Incomplete reporting of results
Garrett et al. (1999a, 1999b); (Australia) Residences: children (prevalence study) | | 4-day household samples (4 seasons), multiple locations; up to 0.139 mg/m^3^. Protocol discussed. Separate paper about exposure measures. 74% of children had lived in same house for at least 5 years. | Asthma: Parent report of doctor-diagnosed asthma. Mean score 4.6 in asthma cases, 0.7 in controls on respiratory symptom questionnaire completed at last home visit (symptom frequency, 4 categories, over past year of: cough, cough in the morning, shortness of breath, waking due to shortness of breath, wheeze/whistling, asthma attacks, chest tightness, and chest tightness in the morning). | Adjusted for parental asthma history, sex; other factors examined but not needed in final model (passive smoke, pets, indoor NO_2_, fungal spores, house dust mite allergens) | For asthma, incomplete reporting of results (adjusted results reported as “not statistically significant”) | N = 145 in allergy analysis; 53 cases, and 95 controls in asthma case-control analysis
Herbert et al. (1994); (Canada) Wood workers (prevalence study); Related reference: Herbert et al. (1995) | Oriented strand board manufacturing, mean duration 5.1 years. Referent group = oil field workers, not exposed to gas or vapors, mean duration 10.0 years. Participation rate 98% in workers, 82% in comparison group. 99 exposed, 165 referents. Because both groups are “exposed” workers, healthy worker effect unlikely. Some uncertainty about effect of exposures in the referent group | Area samples. 21 hrs continuous sampling on 2 separate d); range 0.090 to 0.330 mg/m^3^ | Allergy and asthma: Exposure measurement blinded to outcome classification | Possible respiratory irritants in comparison group (oil sands workers); Adjusted for age and smoking; dust measured and reported as low, not included in analysis | Logistic regression, OR (95% CI); prevalence of “outcome” (positive responders) not reported | N = 99 exposed; 165 referents | Allergy (skin prick tests); Low; Selection out of the exposed work force of “affecteds” possible in this type of prevalence study. Uncertainty about exposures in referent group. Uncertainty about time window of exposure measurement with respect to skin prick test results in adults.; Asthma; Medium (↓); Selection out of the exposed work force of “affecteds” possible in this type of prevalence study, and Uncertainty about exposures in referent group. Either limitation could result in reduced (attenuated) effect estimate.
Herbert et al. (1994); (Canada) Wood workers (prevalence study); Related reference: Herbert et al. (1995) | | Area samples. 21 hrs continuous sampling on 2 separate d); range 0.090 to 0.330 mg/m^3^ | Allergy: 6 allergen skin prick test (wheat, rye, Alternaria, cat, house dust, birch). | Possible respiratory irritants in comparison group (oil sands workers); Adjusted for age and smoking; dust measured and reported as low, not included in analysis | Logistic regression, OR (95% CI); prevalence of “outcome” (positive responders) not reported | N = 99 exposed; 165 referents
Herbert et al. (1994); (Canada) Wood workers (prevalence study); Related reference: Herbert et al. (1995) | | Area samples. 21 hrs continuous sampling on 2 separate d); range 0.090 to 0.330 mg/m^3^ | Asthma: International Union Against Tuberculosis and Lung Disease (1986) questionnaire, described and validated in (Ravault and Kauffmann, 2001): (asthma; lower respiratory tract symptoms (list includes woken by shortness of breath; attacks of wheeze, wheeze with chest tightness.) [increased prevalence of lower respiratory tract symptoms associated with lower FEV_1_ or FEV_1_/FVC in these workers]. Time frame of asthma definition interpreted to be relevant | Possible respiratory irritants in comparison group (oil sands workers); Adjusted for age and smoking; dust measured and reported as low, not included in analysis | Logistic regression, OR (95% CI); prevalence of “outcome” (positive responders) not reported | N = 99 exposed; 165 referents
Holness and Nethercott (1989); (Canada) Funeral home workers (prevalence study) | Participants recruited from list of funeral homes, 86.6% participation; 79.8% of embalmers were active embalmers (healthy workers); community referent (service organization and students)—potential differences (weight, smoking) | 2 area samples (impingers), during embalming, 30 to 180 min. Range in exposed 0.10–1.0 mg/m^3^, referent mean 0.025 mg/m^3^; adequate exposure contrast likely for comparison of exposed and referent. | American Thoracic Society (Ferris, 1978) questionnaire: wheeze (no details of questions) | Univariate analysis; did not consider other variables and referent may not be comparable to exposed with respect to possible confounders | Frequency by group and p-value from a logistic regression | N = 84 exposed; N = 38 referents | Asthma; Low; Uncertainty regarding asthma definition. Differences in source populations for exposed and referent groups lead to uncertainty in comparability. No consideration of potential confounding.
Hsu et al. (2012); (Taiwan) Residences: children (case-control) August 2008–September 2009 | Initially recr through randomly selected kindergartens and day care centers; Mean age 7.0 years. 73% of successfully contacted agreed to send questionnaires to families and 68% of the questionnaires were completed. Selected for follow-up if had not moved or renovated house since birth. Of the 980 potential cases and 802 potential controls selected, 267 (27%) and 89 (11%) participated in clinical exam; 59 cases and 42 controls (22% and 47% of cases and controls, respectively, completing exam) also completed home exposure measures. | 2-hr household sample (probably bedroom); Median 0.076 mg/m^3^; 75^th^ percentile 0.25 mg/m^3^; Limited sampling period with no information on protocol. | Initial screening through parent report of history of 2 or more diseases (asthma, allergic rhinitis) or symptoms (wheezing, coughing at night, eczema, sneezing, runny or stuffy nose) during last 12 mos; confirmation of asthma, rhinitis, and eczema by clinical examination. Controls answered “no” to all of the disease and symptom questions. Exposure measurement blinded to outcome classification | None addressed in analysis. Similar season distribution in cases and controls | Mann-Whitney U test for case-control differences in exposure distribution. Median, 25^th^ and 75^th^ percentiles given for cases and controls. P-values reported if <0.10. No additional modeling of the formaldehyde data undertaken | N = 48 allergic rhinitis, 36 eczema, 9 asthma cases, and 42 controls | Allergy (rhinitis, eczema) and asthma; Low; Low and differential (at various steps) participation rate. Limited exposure sampling period and no information on protocol. In addition, small sample size (n = 9) for asthma.
Huang et al. (2017); (Shanghai, China) Residences: children (case-control) March 2013–December 2014 | Participants in a previous crosssectional study (2011–2012) selected from 88 kindergartens located in 6 Shanghai districts (note: references for cross-sectional study stated 72 kindergartens selected in 5 districts, N = 14,884). Included if homes were not renovated in the previous 2 years and agreed to an on-site home inspection, N = 454 residences, 4.5% of cross-sectional survey for 10,182 participants with contact information (409 of 454 residences assessed), 5–10 years old. | Continuous formaldehyde sampling in child’s bedroom, 24 hrs, in breathing zone (detection range: 0.012-0.08 mg/m^3^). Mean (SD) concentration (mg/m^3^), 24-hr 0.0215 ± 0.0130; 75th percentile 0.0275 mg/m^3^ Range 0.006–0.06 mg/m^3^, with 3 bedrooms higher | ISAAC questionnaire, translated (selected questions) Current rhinitis: In the past 12 mos, has your child had a problem with sneezing, or a runny, or a blocked nose when he/she did not have a cold or the flu? Current eczema: In the past 12 mos, has your child had an itchy rash (eczema), which was coming and going for the last 6 mos? Current wheeze: Has your child had wheezing or whistling in the chest in the last 12 mos? | Covariates considered in models based on literature and previous analyses, included age, sex, family history of atopy, family annual income level, household ETS, household dampness-related exposures, antibiotics exposure during 1^st^ year of life, home decoration around time of birth, season of sampling. Higher proportion of homes with mechanical ventilation among current rhinitis cases compared to controls (77.5% versus 65%) | Differences between cases and controls compared using Kolmogorov-Smirnov test. Multiple logistic regression models per IQR increment or quartile of formaldehyde concentration. | N = 409 | Current rhinitis; Medium; Low participation rate, but potential for differential participation (by formaldehyde exposure and disease status) uncertain; uncertainty regarding validation of truncated version of ISAAC questionnaire in this population; Eczema and Asthma; Low; Low participation rate, but potential for differential participation (by formaldehyde exposure and disease status) uncertain; larger uncertainty regarding truncated questions.
Hulin et al. (2010); (France) Residences: children (case-control) | 2 samples: urban area, French 6 Cities Study (ISAAC). Random selection of 18 schools; nested case-control study of asthma Rural area; nested case-control study of asthma (FERMA) (rural sampling for regular contact with farm animals) Examined nonparticipants | 7-d sample in living room. Protocol discussed. Median 0.019 mg/m^3^, maximum 0.075 mg/m^3^ | Ever asthma and current asthma (parent report of use of asthma medications or wheezing in past 12 mos). Exposure measurement blinded to outcome classification | Adjusted for age, sex, family history of allergy, passive smoke exposure during childhood, allergic rhinitis, and season. Considered nonindependence of participants in similar neighborhood. Assessed collinearity with other measures (NO_x_, PM_2.5_) | OR (95% CI) by above and below median. Also included analysis stratified by location (urban, rural) | Urban: (N = 32 cases, 31 controls). Rural: (N = 24 cases, 27 controls). Combined: N = 56 cases, 58 controls (but 9 rural and 7 urban excluded, unspecified number excluded from analysis limited to current asthma | Asthma; Low; Small sample size and uncertain interpretation of the stratified analyses (and unspecified n in analysis of current asthma).
Hwang et al. (2011); (Korea) Residences: children (case-control) May 2008 | Case-control study, drawn from 1,005 elementary students (one school, all grades) (84% participation rate). 33 cases (out of 129?) and 40 controls (out of unspecified number) agreed to participate in environmental measurement study. Controls selected from respondents with no asthma symptoms or diagnosis, age and sex matched to cases. | 3-d household sample (2 rooms) and personal sample. Geometric mean, controls: 0.036 mg/m^3^ (no information on upper distribution reported). | Self-report asthma symptoms or physician-diagnosed asthma based on ISAAC questionnaire (no mention of modification or validation for this population) | Adjusted for age, gender, income, parents’ education, passive smoking | Log-transformed; logistic regression, OR (95% CI) | N = 33 cases, 40 controls | Asthma; Low; Asthma definition does not distinguish between current asthma and ever asthma. Uncertainty regarding selection processes [high prevalence of family history of asthma in cases (86%) and controls (96%)]; uncertainty about analysis and distribution of formaldehyde levels.
Isa et al. (2020a); (Malaysia) Schools: children (prevalence study) August–November 2018 & February 2019 | 8 randomly selected schools in Hulu Langat, Selangor, Malaysia, randomly selected students from 4 classes (Form 2, aged 14 years). Data collected Nov 2018–February 2019. Excluded students reporting smoking in last 12 months or treated with antibiotics in last 4 wks. Participation rate not reported but was 96% in similar study in other parts of Malaysia using similar design [Morback 2017 ref] | Formaldehyde concentrations measured during class time using PPM Formalde-meter (accuracy of 10% at 2 ppm). Monitors 1 meter from ground in center, four 1-hr periods. Concentration (reported as mg/m^3^, but appears to have been µg/m^3^) median (IQR) Urban 13.2 (9.3); Suburban 3.1 (5.2) Uncertainty in concentrations given short sampling duration | Asthma & allergy information and symptoms within defined period using ECRHS and ISAAC questionnaires. Responses were blind to environmental data. Allergy skin prick test for mites, fungi and cat allergens after 15 min measuring wheal diameter (atopy defined as ≥ 3 mm). Respiratory symptoms in last 12 mos: wheezing, daytime breathlessness, nocturnal attacks of breathlessness. Allergic symptoms in last 12 mos: rhinitis, skin allergy. | Regression models controlled for atopy, sex, doctor’s diagnosed asthma, parental asthma/allergic and location of schools. | 2-level hierarchic multiple logistic regression (school and student), OR (95% CI), adjusting for personal factors and environmental pollutants associated with each outcome. | N = 470 | Allergy (rhinitis, dermal, skin prick tests); Low; Uncertainty in exposure concentrations and distribution given short sampling duration; very low concentrations in half (suburban) schools.
Kim et al. (2011); (Korea) Schools: children (prevalence study) November–December 2004 | 12 schools, 2–3 randomly selected classrooms per school Participation rate 96%; 450 excluded based on missing data) | 7-d samples in classrooms. Mean (±SD), (minimum, maximum) 0.028 (±0.0083) 0.016, 0.047 mg/m^3^. Protocol discussed, closed windows. | Current medication use or had asthma attack in past 12 mos. Exposure measurement blinded to outcome classification | Adjusted for age, sex, self-reported pet or pollen allergy, environmental tobacco smoke at home, other home environment (indoor dampness, remodeling, changing floor, age of home). All samples within same season. | Logistic regression, OR (95% CI) per 10 µg/m^3^ increase; additional modeling to account for within school and within city correlations. | N = 1,028 | Asthma; High
Krzyzanowski et al. (1990); (United States, Arizona) Residences: adults, children (prevalence study); Supplemental references: Quackenboss et al. (1989a); Quackenboss et al. (1989b) | Selected from 202 households (stratified sample from municipal employees). 2,322 completed baseline survey; subgroups selected based on housing characteristics (type, age, remodeling). Clusters within similar outdoor PM and pollen levels. Participation rate not reported but sampled nonresponders: higher proportion of current smokers among refusals (35% versus 27%) | Two 1-wk household samples (different seasons), multiple locations; Mean 0.032 mg/m^3^; maximum 0.172 mg/m^3^ (most <0.074, only a few above 0.110 mg/m^3^) Protocol discussed (separate paper). | Asthma: American Thoracic Society (Ferris, 1978) questionnaire; doctor-diagnosed asthma (ever and current) and symptom questions: wheezing apart from colds, 2 or more attacks of shortness of breath with wheezing in last year. Exposure measurement blinded to outcome classification | Environmental tobacco smoke. Also examined NO2 | Contingency tables, stratified by age group and for children, by environmental tobacco smoke exposure. For adults, incomplete reporting of results. | Adults: N = 613 Children: N = 298 | Asthma, children and adults; Medium; For children, relatively small # (n = 21) in higher exposure categories. For adults, incomplete reporting of results.
Lajoie et al. (2014); (Quebec, Canada) Intervention study October 2008 – June 2011 | Asthmatic children with exacerbation requiring medical care in the past year referred by physicians at tertiary care center, 3–12 years old, mean age 6 years (n = 83, 71.5% of those meeting inclusion criteria) in homes with low ventilation rates (<0.30 ACH). Randomly assigned to intervention to increase ventilation rates by 0.15 ACH (n = 43) and control (n = 40). | Pre- and post-intervention. Passive air sampling for formaldehyde in bedroom, 6-8 d, during winter and summer seasons. Other measurements for N0_2_, VOCs, dust, house dust mites, cat and dog allergens, airborne mold spores. In controls, mean 0.037 mg/m^3^ 25^th^ percentile 0027 mg/m^3^ 75^th^ percentile 0.051 mg/m^3^ | Variable number with complete data for each outcome. Participants were not blinded, although technicians were. Formaldehyde-specific Intervention/Control Proportion with ≥ 1 episode of wheezing over last 12 mos, ISAAC questionnaire administered to parents: 43/39; Mean number of days with asthma symptoms per 14 d period (≥ 1 coughing, wheezing, chest tightness, disturbed sleep or trouble breathing Symptoms diary: 37/32; administered to parents 2 wks per month from November–March in 2010 and 2011; Asthma control over one month, Asthma quiz: 31/25; | Potential confounders for asthma outcomes were age, gender, parents’ level of education, and eczema. Comparing baseline concentrations formaldehyde, NO_2,_ and dust mites were comparable, Toluene and mold spores were higher in intervention group. Comparing year 1 to 2, reductions in formaldehyde, toluene, styrene, limonene, and alpha-pinene, airborne mold spore concentrations were significantly different for intervention group compared to control. NO_2_ concentrations increased. Allergens in mattress and rugs in bedroom did not change. | Power calculation reported. Multivariate linear models Formaldehyde analyses used results in intervention group only. Change from year 1 to year 2 in prevalence of asthma symptoms and medical care in the past year associated with a 50% reduction in formaldehyde concentration analyzed using mixed linear models with repeated measures | For ISAAC questionna ire, interventio n N = 43, control = 39 | Current asthma symptoms; Medium; Other coexposures that have been associated with asthma symptoms also declined in intervention group (toluene, ethylbenzene, styrene, limonene, alpha-pinene, airborne mold spores, although formaldehyde reduction was greatest
Liu et al. (2018a); (China) Hospital based case-control: children September 2016 to March 2017 | Recruited 180 children with an asthma diagnosis from hospital and 180 healthy controls in same city (Changchun) during September 2016 to March 2017; mean age 10 years. Information on participation rate not provided but the “pass rate” of the questionnaire was 100% and equal number of cases and controls. Children excluded if medical treatment with vitamins or antibiotics within 3 mo, severe organ failure (heart, renal and other serious disorders). | Indoor area samplers placed 1–1.5 meters above ground, doors and windows closed 12 hrs prior. HCHO sampled in living room and bedroom with QC-2B sampler, Beijing Municipal Institute of Labor Protection method. Citation for method provided. Sampling period was 2 mos. Median (range) µg/m^3^ HCHO Asthma 38.35 (12.04 – 142.12) Control 25.11 (12.26–94.34) NO_2_ and PM also measured. | Current asthma symptoms (2 or more of cough, wheezing, and dyspnea for three or more consecutive days) based on ISAAC questionnaire; responses (2 or more incidents of cough, wheezing, and dyspnea for 3 or more consecutive d). In addition, FEV_1_ increased by >15% after β-agonist inhalation and persistent asthma was stable for 3 or more mos prior to study. Serum miR-155 also used as measure of asthma. | History of allergy, breast feeding, ETS and indoor plants were associated with asthma status. Included in model with PM_2.5_ and HCHO. Sex, mean age, mean BMI and race were comparable between cases and controls. | Associations with pollutant concentration (quartiles, entered as a single variable) analyzed with multivariate regression. Coexposures to PM and NO_2_ were simultaneously controlled. | N = 180 cases; 180 controls | Current asthma symptoms; Medium; Uncertainty regarding interpretation of formaldehyde as a single variable representing 4 quartiles.
Madureira et al. (2016); (Porto, Portugal) Children, case-control, October 2012–April 2013 | Random recruitment of 38 residences among asthmatic children and 30 residences among nonasthmatic children previously identified in a cross-sectional study (Madureira et al., 2015). Mean age 8.5 years. Excluded respondents with a recent renovation or who had moved since responding. No information comparing participants to nonparticipants. Potential exists for selection bias with greater environmental controls among asthmatic families. Although extent of bias impact unknown, TVOCs, acetaldehyde and ventilation rates higher in control homes, but not PM or bacteria and fungi counts. | Continuous passive sampling for formaldehyde and other VOCs and aldehydes in bedroom over 7 d; PM2.5, PM10, bacteria, fungi, carbon dioxide (CO_2_), temperature and relative humidity levels also measured both indoors and outdoors. Sampling and analysis methods described. Formaldehyde concentrations all above the detection limit. Controls mean (sd) 0.016 (0.009) mg/m^3^ 25th percentile 0.009 mg/m^3^ 75th percentile 0.022 mg/m^3^ Median 0.015 mg/m^3^ | For asthma cases, parents responded yes to both of 2 questions in ISAAC questionnaire: (1) Has your child ever had asthma diagnosed by a doctor? and (2) In the past 12 mos, has your child had wheezing or whistling in the chest? Parents of controls responded no to both questions. | Higher proportion of cases were boys. Comparable for age, BMI and parental education level, family history of allergic disorders and number of siblings was slightly higher in cases. No other chemical or biological risk factors differed between groups (except limonene was higher in control). | Concentrations (7-d means) compared between groups (unclear what test was used, other than Shapiro-Wilk test for normality before comparison. Differences in temperature and relative humidity not addressed in analysis. | Cases N = 38 Controls N = 30 | Current Asthma; Low; Potential for selection bias, with greater environmental controls among asthmatic families. Differences in temperature and relative humidity not addressed in analysis.
Malaka and Kodama (1990); (Indonesia) Wood workers (prevalence study) | Plywood mill workers, random sample of exposed workers (based on measurements), stratified by smoking, work duration (<, ≥ 5 years), (random sampling process not specified). Random sample of nonexposed (defined based on area measures and job history), matched to exposed by age, duration, and smoking. 93% participation rate and mean duration about 6 years in both groups. | Personal and area samples (duration not reported); above 200 (mean 910, up to 3,480 µg/m^3^). Nonexposed areas based on measurements (e.g., warehouse, saw mill) | American Thoracic Society (Ferris, 1978) questionnaire. Asthma defined as “Ever had attack of wheezing that made you feel short of breath?” or ever had asthma and if so, do you currently have asthma? Also included “occupational asthma” (not defined). Since purpose of study was the impact of occupational exposure, asthma definition is interpreted to be relevant to current status. [Increased prevalence of asthma associated with lower FEV_1_ or FEV_1_/FVC in these workers]. | Adjusted for age, smoking, dust | Percent by exposure status, OR, p-value 95% CI not reported (but could be calculated for crude OR estimate) | N = 93 exposed; 93 referents | Asthma; Medium; Selection out of the exposed work force of “affected” possible in this type of prevalence study. “Unexposed” exposure group exposed to levels of formaldehyde up to 0.086mg/m^3^. Either limitation could result in reduced (attenuated) effect estimate. Unclear definition of asthma used in the analysis: Occupational asthma” not defined, and lack of clarity in asthma definition pertaining to current prevalence.
Matsunaga et al. (2008); (Japan). Residences: adults (Prevalence study) | Pregnancy cohort, enrolled 2^nd^ trimester. Recruited through pregnancy clinics and obstetrics departments. 17% of pregnant women in the city participated; recruitment extended to other areas. Low participation rate. Internal comparison group. | 24-hr personal sample; 60^th^, 90^th^ percentile and maximum: 0.033, 0.058, and 0.161 mg/m^3^ | Exposure measurement blinded to outcome classification. | Adjusted for age, gestation, parity, family history (of asthma, atopic eczema, allergic rhinitis), smoking status, current passive smoking at home and work, mold in kitchen, indoor domestic pets, dust mite antigen level, family income, education, and season of data collection. Also examined NO_2_ | Logistic regression, OR (95% CI) by 4 exposure categories (30th, 60th and 90th percentiles); also presented dichotomized at 90^th^ percentile. Results also stratified by family history of allergies. | N = 998; 21 asthma cases, 57 eczema, 140 rhinitis cases | Allergy (atopic eczema, rhinitis) and asthma; Medium; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. Some uncertainty pertaining to sensitivity and specificity of outcome assessments.
Matsunaga et al. (2008); (Japan). Residences: adults (Prevalence study) | | 24-hr personal sample; 60^th^, 90^th^ percentile and maximum: 0.033, 0.058, and 0.161 mg/m^3^ | Allergy: Self-report of medical treatment (medication use) for atopic eczema or allergic rhinitis in past 12 mos.; Asthma: Self-report of medical treatment (medication use) for asthma in past 12 mos. | | Logistic regression, OR (95% CI) by 4 exposure categories (30th, 60th and 90th percentiles); also presented dichotomized at 90^th^ percentile. Results also stratified by family history of allergies. | N = 998; 21 asthma cases, 57 eczema, 140 rhinitis cases
Mi et al. (2006); (China) Schools: children (prevalence study) November–December 2011 | 10 schools, 3 classrooms (7^th^ grade) per school. Participation rate 99% | 4-hr (school day) air samples from 30 classrooms; protocol discussed. Minimum = 0.003 mg/m^3^; (unclear if this is ½ of LOD?; 1 SD above mean = 18 µg/m^3^; maximum = 20 µg/m^3^. | ECRHS questionnaire, Medication use or asthma attack in past 12 mos; additional questions on lower respiratory tract symptoms (in past 12 mos, wheeze or whistling in the chest, daytime breathlessness attack at rest or after exercise, nighttime breathlessness attack). Exposure measurement blinded to outcome classification | Adjusted for age, gender, smoking, observed water leakage and indoor moulds. Also examined temperature, relative humidity, indoor CO_2_, indoor O_3_, and examined collinearity of exposures. | Logistic regression, OR (95% CI) per 0.010 mg/m^3^ increase. Uncertainty about exposure distribution and analysis (e.g., percent <LOD and treatment in analysis as continuous variable) | N = 1,414 | Asthma; Low; Short exposure measurement period and uncertainty about exposure distribution and analysis (e.g., percent <LOD and treatment in analysis as continuous variable)
Neamtiu et al. (2019); (Romania) Children: schools | Schools Indoor Pollution and Health: Observatory Network in Europe (SINPHONIE) project, 2010 to 2012. The authors analyzed the data for Romania, which included 5 primary schools in one county (2 rural, 3 urban), and 3 classrooms per school were selected. Questionnaire responses for October to December 2011 for 139 male and 141 female students; 89.7% response rate for children | Formaldehyde measured in each classroom, 5 d sampling period. Passive samplers, Radiello cartridges, impregnated with 2,4-dinitrophenylhy drazine using ISO 16000-2 protocol. Analysis within 48 hrs using a validated method from European Commission. Detection limit was 0.1 µg/m^3^; median = 0.035 mg/m^3^; maximum = 0.066 mg/m^3^; 75^th^ percentile = 0.045 mg/m^3^ | ISAAC questionnaire.; Allergy-like symptoms in past week: defined as skin conditions (e.g., rash, itch, eczema), eye disorders (e.g., red, dry, swollen, itching, or burning eyes, or sensation of “sand in the eyes,” and rhinitis symptoms (e.g., itching nose, sneezes, and/or stuffy or blocked Nose). | Analyses controlled for age, sex, ETS in the past week, microclimate parameters (NO_2_, CO, CO_2_, temperature, relative humidity, ventilation rate. | Multivariate analysis of formaldehyde categorized as high (> 35 µg/m^3^) and low (≤ 35 µg/m^3^) based on the median. | N = 280 | Asthma-like symptoms,; Allergy-like symptoms; Medium; Outcome definition for allergy-like symptoms using ISAAC questionnaire included combined symptoms of rhinitis (nose), eye and skin conditions, which could mask an effect in one of these categories; skin condition question not specific for eczema. Asthma-like symptoms limited to the past week.
Neamtiu et al. (2019); (Romania) Children: schools | | | Asthma-like symptoms: defined as difficult breathing, dry cough and wheezing in the past week (any symptom. | Analyses controlled for age, sex, ETS in the past week, microclimate parameters (NO_2_, CO, CO_2_, temperature, relative humidity, ventilation rate. | Multivariate analysis of formaldehyde categorized as high (> 35 µg/m^3^) and low (≤ 35 µg/m^3^) based on the median. | N = 280
Neghab et al. (2011) (Iran) Workers: melamine-formaldehyde resin plant (prevalence study) | Exposed: melamine-formaldehyde resin plant workers. Referent group: office workers from same plant, no present or past exposure to formaldehyde or other respiratory irritant chemicals. Participation rate 100%. Duration ≥2 years | Area samples (40 min) in 7 workshops and 1 area sample in office area. Exposed (mean ± SD) 0.96 (±0.49) mg/m^3^; unexposed = nondetectable. | American Thoracic Society (Ferris, 1978) questionnaire (modified): wheezing symptoms (no details of questions) | No covariates considered in the symptom analysis. Similar in demographics and current smoking (but smoking frequency higher among exposed) | Fisher’s exact test, OR (p-value) | N = 70 exposed, 24 unexposed | Asthma; Low; Selection out of the exposed work force of “affecteds” possible in this type of prevalence study; could result in reduced (attenuated) effect estimate. Potential low specificity and low sensitivity of outcome measure; no covariates considered in analysis.
Norback et al. (1995); (Sweden) Residences: adults (nested case-control) | Recruited from 154 randomly selected members of general population; 64% participation rate for cases, 57% for controls | 2-hr household sample (bedroom). Limited sampling period in closed residence with no point formaldehyde emissions; sampling and analytic protocols referenced Andersson et al. (1981), Mean (Min, Max) 0.029 (<0.005, 0.110) mg/m^3^; LOQ = 0.1 mg/m^3^) | Positive response to: asthma attack in past 12 mos, nocturnal breathlessness in past 12 mos, or current use of asthma medication. Controls answered no to all questions | Adjusted for age, sex, current smoking, wall-towall carpets, and house dust mites. Formaldehyde measure reported to be strongly correlated with total volatile organic compounds. | Log-transformed, logistic regression, OR (95% CI) per 0.001 mg/m^3^ increase. Mean subtracted from each observation to reduce collinearity with VOCs | N = 47 cases, 41 controls | Asthma; Low (↑); Uncertainty about exposure (most values <LOQ). Similar results for volatile organic compounds, and not possible to distinguish effects of formaldehyde and these other compounds; could result in inflated effect estimate.
Norbäck et al. (2017); (Malaysia) Schools: children 2007 | 8 randomly selected schools in Johor Bahru, Malaysia, randomly selected 15 students each from 4 randomly selected classes (Form 2, aged 14 years). Data collection in 2007. Participation 96% | Sampling and analytical methods were described. Formaldehyde sampled continuously over 7 d in each classroom using diffusion samplers. Samplers placed 2 meters above floor. Mean concentrations formaldehyde indoor 4.2 µg/m^3^, max 18.0 µg/m^3^, 100%>DL Outside 5.5 µg/m^3^, max 6.0 µg/m^3^, 100%>DL. Combined indoor and outdoor measures used in the analysis. | Standardized questionnaire completed by students with parents blinded to environmental measurements. Rhinitis defined by 2 questions combined regarding nasal catarrh or nasal congestion. Ocular symptoms defined on one question on ocular symptom (dry eyes or itchiness in the eyes). Cases defined by reporting symptoms weekly over a 3-mo period. | There were no significant correlations between CO_2_, NO_2_ or formaldehyde and any of the measured VOC. Models adjusted for other indoor chemical exposures, personal factors and home environment factors. | Stepwise multiple logistic regression for symptoms including indoor exposures (CO_2_, NO_2_, formaldehyde and VOC personal factors (sex, race, current smoking, atopy, parental asthma/allergy) and home environment factors (ETS, dampness/mold, recent indoor painting). 3-level logistic regression models (child, school, classroom) including significant exposure variables from first model, all personal factors and all environment factors. Quantitative results not reported for formaldehyde if not statistically significant. | N = 462 | Allergy; Medium; Results for rhinitis were reported as “not statistically significant” without providing quantitative effect estimates. Very low indoor formaldehyde concentrations
Palczynski et al. (1999); (Poland) Residences: adults, children (prevalence study) | Random sample of 120 households with children ages 5–15 years, built 10 years before study. Participation rate not reported (i.e., were more than 120 households originally recruited?) | 24-hr household sample, area not specified; Mean (±SD) (minimum, maximum): 0.026 (±0.011) (0.002, 0.067) mg/m^3^; 2% > 0.050 mg/m^3^ Calibration: 0.005 to 0.100 mg/m^3^ | Allergy: 5 allergen skin prick test (dust, dust mites, feathers, grasses); serum IgE positive if ≥ 0.35 kU/l RAST (uncertainty regarding time window of exposure for this outcome in adults | Environmental tobacco smoke | Contingency table analysis, prevalence (n, %) by age (adult; children) exposure group, and environmental tobacco smoke exposure. Highest exposure group very sparse. | N = 278 adults, 186 children | All outcomes; Not informative above 0.050 mg/m^3^ because of sample size (≤5).; Allergy (skin prick tests), children; Medium; .; Allergy (skin prick tests) in adults; Low; Uncertainty about time window of exposure measurement with respect to skin prick test results in adults. (greater uncertainty in adults than in children);; Asthma, children and adults; Medium; Uncertainty regarding asthma definition
Palczynski et al. (1999); (Poland) Residences: adults, children (prevalence study) | Random sample of 120 households with children ages 5–15 years, built 10 years before study. Participation rate not reported (i.e., were more than 120 households originally recruited?) | 24-hr household sample, area not specified; Mean (±SD) (minimum, maximum): 0.026 (±0.011) (0.002, 0.067) mg/m^3^; 2% > 0.050 mg/m^3^ Calibration: 0.005 to 0.100 mg/m^3^ | Asthma: Bronchial asthma diagnosis based on American Thoracic Society criteria (Ferris, 1978) (additional details not reported). Diagnosis interpreted to be for current status. Exposure measurement blinded to outcome classification | Environmental tobacco smoke | Contingency table analysis, prevalence (n, %) by age (adult; children) exposure group, and environmental tobacco smoke exposure. Highest exposure group very sparse. | N = 278 adults, 186 children
Smedje and Norback (2001); (Sweden) Schools: children (nested case-control design) 1993–1997; Related reference: Smedje et al. (1997); however, this baseline study of prevalence of current asthma used measures taken in 1993, which ranged from <0.005 to 0.010 mg/m^3^, with >50% less than LOD. Thus, this analysis did not meet EPA’s inclusion criteria. | Nested case-control in school-based cohort study, 1^st^, 4^th^, and 7^th^ grades at baseline (1993); follow-up in 1997. Excluded if history of allergy at baseline. 78% participation in follow-up. Schools randomly selected in Uppsala, Sweden; 2–5 classrooms selected from schools for exposure measures. Participants compared to nonparticipants on baseline characteristics. | 4-hr (school day) samples, 2–5 rooms per school (chose frequently used rooms), 1993 and 1995; <0.005 to 0.042 mg/m^3^. Mean 0.008, geometric mean 0.004 mg/m^3^ | Allergy: Parent report of incident allergy to hay fever/pollen or pet dander. Asthma: Parent-report of incident physician diagnosis (validation study: specificity >99%, sensitivity 73% compared with physician’s assessment). Exposure measurement blinded to outcome classification | Adjusted for age, sex, history of atopy (eczema) at baseline, changes in smoking habits. Collinearity among measures (including VOC, mold) assessed; did not attempt adjustment for multiple exposures but pattern of results differed among the exposures examined. | Logistic regression, OR (95% CI) per 0.010 mg/m^3^ increase [high proportion below detection limit of 0.005 mg/m^3^, 54% of 1993 samples and 24% of 1997]. Results were reported to be similar when students who were no longer in the school were excluded (about 2/3 left the school at mean of 1.5 years before follow-up) | N = 88 incident pollen allergy; 50 incident pet allergy cases; 56 incident asthma cases out of 1,258 at baseline. | Allergy (incidence of allergies) and asthma (incidence); Low; Exposure measures in only 2 of the 4 years and 2/3 of students left the school more than a year before follow-up; uncertainty about distribution; relatively high percentage <LOD. Confounding by other exposures not fully addressed but pattern of results differed among the exposures examined.; (Information on percent below detection limit and individual student exposures provided in email from Dr. Greta Smedje, March 22, 2012)
Tavernier et al. (2006); (United Kingdom) Residences: children (case-control); Related reference: Gee et al. (2005) | Cases from 2 primary care practices, age- and sex-matched controls from same practices. Ages 4–16 years. Participation rate 50%. 95 additional cases excluded because no matching control identified. [Note: Gee et al. (2005) described the age range as 4–16 years] | 7-d sample in living room and bedroom. Did not report any information on exposure distribution. [Note: Gee et al. (2005) described this as a 5 d sample; median values 0.037 and 0.049 mg/m^3^ in living room and bedroom, respectively] | Positive responses to three questions on screening questionnaire: (1) wheezed in the last 12 mos; (2) woken at night by cough in the absence of a cold or respiratory infection in the last 12 mos; (3) received more than 3 courses of antibiotics for respiratory symptoms (both upper and lower respiratory tract) in the last 12 mos; (4) history of hay fever or eczema; (5) family history of asthma in first degree relatives. In validation study, positive predictive value 84% for meriting trial for asthma medication. Exposure measurement blinded to outcome classification. [Note: Gee et al. (2005) described the positive predictive value from the validation study as 79%] | Adjusted for measured exposures (e.g., endotoxin, Der p 1, particulate matter, NO_2_, and other risk factors. | Logistic regression, OR (95% CI) by tertile (but exposure levels by tertile not reported) | N = 105 cases, 95 controls | Asthma; Low; Uncertainty regarding selection process and loss of almost half of the cases. Outcome classification includes questions that are not specific to asthma. Uncertainty as to exposure range, particularly upper tertile (no response from email to corresponding author).
Venn et al. (2003); (United Kingdom) Residences: children (nested case-control and symptom control among cases) October–May 1998 | Participants in air pollution study 1993–1995, 85% response rate; 835 potential cases (positive wheeze question) and 860 potential controls recontacted in 1998; 54% responded. ages 9–11 years. From this, 243 eligible cases and 383 eligible controls identified. Participation rate 79% cases, 59% controls.; Supplemental reference:Venn et al. (2000) | 3-d sample in bedroom in 1998 concurrent with data collection on outcomes; median 22 µg/m^3^; 75th percentile 32 µg/m^3^ | Asthma: Parent report of persistent wheeze (1995–1996 and 1998); validation by medical record review of prescription for asthma medication. Symptom frequency: 1 mo daily diaries recording symptoms, including daytime and nighttime wheezing, chest tightness, breathlessness, and cough, each measured on 0 to 5 scale. Exposure measurement blinded to outcome classification | Adjusted for age, sex, Carstairs deprivation index (based on postal code). Also examined and addressed other variables, including NO_2_, moisture, mold, season. No evidence of an adverse effect of NO_2_ or VOCs other than formaldehyde on children’s respiratory health. | Logistic regression, OR (95% CI) by quartile. Examined effect modification of symptom frequency by atopy | N = 190 cases, 214 controls | Asthma; Medium; Uncertainty regarding impact of loss of subjects between 1995 and 1998.; Asthma control; High
Yeatts et al. (2012); (United Arab Emirates) Residences (survey) October 2009 to May 2010 | Nationally representative sample of households, stratified by geographic area and population density. 628 households, household participation rate 75%. Age-stratified sample selected from households. | 7-d sample in living room. 71% <LOQ (0.0074 mg/m^3^); 95^th^ percentile 0.059 mg/m^3^; 99^th^ percentile 0.114 mg/m^3^ (converted from ppm) | Symptom questionnaire (last 4 wks), drawn from standard questionnaires. Mothers responded for children. Exposure measurement blinded to outcome classification | Moderate correlation between formaldehyde and sulfur dioxide (r = 0.63); formaldehyde strongly associated with frequency of incense use. Adjusted for sex, urban/rural area, age group, household tobacco smoke exposure. | Logistic regression, above versus below detection limit, OR (95% CI). Does not separate analysis of children and adults; only 29% above LOD—analyzed as above versus below LOD | N = 1007 adults, 330 ages 11–18 years, 253 ages 6–10 years | Asthma-children and adults (combined); Low (↑); Difficult to disentangle possible effects of sulfur dioxide from those of formaldehyde (similar effect sizes; moderate-strong correlation; could result in inflated effect estimate. Does not report separate analysis of children and adults; only 29% above LOD—analyzed as above versus below LOD
Yon et al. (2019) (Seongnam City, Korea) Prevalence study | 5^th^ and 6^th^ grade students were recruited from 22 randomly selected classrooms at 11 elementary schools (n = 620), aged 10–12 year. 68.9% participation rate. | Formaldehyde sampling in each classroom using monitors with pumps during the 1^st^ and 2^nd^ half of the school year. Mean 0.028 ± 0.0077 mg/m^3^; as high as 0.060 mg/m^3^ in some classrooms. Duration and sampling methods were not described. | Current asthma or rhinitis definition: presence of characteristic symptoms and /or signs during the previous 12 mos using ISAAC questionnaire (some uncertainty regarding validation in this population) Rhinitis severity categorized using Allergic Rhinitis and Its Impact on Asthma guidelines. | Models for asthma or rhinitis adjusted for age and sex a priori. Also adjusted for variables based on statistical significance in model (p < 0.10). Covariates were BMI z-score, height, prematurity or low birth weight, home renovation, environmental tobacco smoke, keeping a pet at home, and physician-diagnosed atopic dermatitis, allergic rhinitis, and parental asthma | Analysis used generalized linear mixed models with robust variance estimates and post hoc Bonferroni correction. Accounted for classroom (random effect) | N = 427 (n = 246 with rhinitis; n = 10 with asthma) | Rhinitis in last 12 months and rhinitis severity; Medium; Uncertainty regarding validation of ISAAC in this population; uncertainty regarding exposure measurement period and other protocol details.; Current asthma; Low; Uncertainty regarding validation of ISAAC in this population; uncertainty regarding exposure measurement period and other protocol details; few (n = 10) children with asthma contributed to analyses.
Zhai et al. (2013); (China) Residences (survey) January 2008 to December 2009 | Provided criteria for selection of homes in defined area; evaluated 186 homes in Shenyang, China; homes were decorated in last 4 years and occupied within the last 3 years. Participation rate of households not reported (i.e., were more than 186 households originally recruited?) Participants within houses were randomly selected | Cited Code for indoor environmental pollution control of civil building engineering (GB50325-2001); samples in 3 rooms per house (bedroom, living room, kitchen); sampling time not specified (no response from email to corresponding author); N = 558 samples in 186 homes. Exposure groups “polluted” homes: >0.08 mg/m^3^, mean 0.09–0.13 mg/m^3^ in three rooms; “nonpolluted” ≤0.08 mg/m^3^, mean 0.04–0.047 mg/m^3^. 64% of the 186 houses, and 24% of the 82 houses with children were >0.08 mg/m^3^ (“polluted”) | Asthma: based on American Thoracic Society (Ferris, 1978) questionnaire | Univariate analysis; confounding unlikely explanation of the results in children | Univariate results for asthma outcome [multivariate modeling of “respiratory symptoms”; not clear what is included in this category) | N = 186 homes 186 adults, 82 children; only n = 2 2 adults with asthma | Asthma, Children; Medium; Uncertainty regarding exposure measurement period. Although potential confounders were not considered in asthma only analysis, the magnitude of the results is unlikely to be explained by confounders.; Asthma, Adults; Low; See notes above, for children. In addition, for adults, small number (n = 2) of positive responses.

#### Epidemiology Studies of Lower Respiratory Symptoms in Infants and Young Children

Table B-36 Evaluation of lower respiratory symptoms in infants and young children (up to age 3 years)

Reference, setting, and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Li et al. (2019); (Hong Kong); Prospective study of birth cohort; September 2013 to April 2014; and; Yu et al. (2017); (Hong Kong); Prospective study of birth cohort; November 2009 to April 2011 | Infants aged < 4 mos attending maternal and child health clinics history of asthma, family history of allergy and no family history. Excluded if congenital disease, cared for at child-care center > 20 hrs/wk, moving after recruitment.; 14 clinics used in 2013–2014 cohort; 29 clinics used in 2009–2011 cohort.; Participation rate 67% in 2013–2014 cohort and 76% in 2009–2011 cohort.; ONo comparisons of participants with nonparticipants. | Air sampling (NO_2_, formaldehyde) using standardized diffusion samplers at 6 mos of age. NO_2_ 10–14 d sampling period.; From Li, 2019: Formaldehyde 72 hr sampling period using ISO 16000-4 method.; Concentrations not reported.; From Yu, 2017 REF: Mean (SD) concentrations Formaldehyde 0.051 (0.075) mg/m^3^ | Baseline information obtained using validated ISAAC questionnaire completed by parents prior to age 4 mos. Weekly respiratory health diary and monthly health telephone survey blinded to exposure status until 18 mos of age.; New onset wheeze (time to event) measured from 6 to 18 mos of age. 120 (12.5%) infants had new onset wheeze at an average of 13.2 mos. | Potential confounders selected from baseline characteristics associated with formaldehyde concentrations using log-rank test, p < 0.25. Stepwise adjustment, final models adjusted for NO_2_, sex, neonatal respiratory illness, having a sibling, family history allergy or asthma, pets, or cooking fuel. | Cox regression in entire sample; formaldehyde modeling as continuous variable | 2013–2014 cohort: N = 963; 2009–2011 cohort: N = 535 | Time to onset of wheeze event; Medium; Low participation rate but potential for differential participation (by formaldehyde exposure and disease status) uncertain. Authors did not respond to queries; EPA assumed exposure measurement details and exposure levels were similar in these 2 studies.
Raaschou-Nielsen et al. (2010); (Denmark); Infants (birth cohort); 1998–2003 | Copenhagen Prospective Study on Asthma in Childhood. 378 out of 411 (92%) participants at 18m o followup; 343 with formaldehyde data. | Three 10-wk bedroom sampling periods from birth to 18 mos (aimed for 6, 12, and 18 mos). Median 0.018 mg/m^3^, 95^th^ percentile 0.037 mg/m^3^.; Within individual variance 69% of total variance | Daily diary kept by parents on respiratory symptoms. Training and definitions provided. Wheezing = any symptom severely affecting the child’s breathing, such as noisy breathing (wheeze or whistling sounds), breathlessness, shortness of breath, or persistent, troublesome cough). Reviewed by study personnel every 6^th^ month and after a 3-d period of respiratory symptoms.; Outcome defined as “ever had at least one symptom day”; sensitivity analysis defined outcome as three or more consecutive days with wheezing symptoms. | Adjusted for sex, area of residence, education of mother, baseline lung function | Logistic regression of “ever had at least one symptom day” (88% = yes) and linear regression of number of symptom days (excluded 78 with 0 d). Analyzed by quintile of exposure (reference = <0.012 mg/m^3^) | N = 343 | Lower respiratory tract conditions in infants and toddlers; Medium; Analysis does not take into account important features of the data (e.g., temporal variations in symptoms and large within individual variability formaldehyde)
Roda et al. (2011); (France); Residences: infants (birth cohort) 2003–2006 | Infants (singletons, >2,500 g) from 5 maternity hospitals in Paris. N = 3,840 out of 4,177 (92%) initially enrolled completed 1 or more questionnaires; 2,940 had baseline and 12 mo questionnaire (70% of initial enrollees; 76% of those with 1 or more questionnaire) | Questionnaire on home characteristics at baseline and updated at 3, 6, 9, and 12 months. N = 196 randomly selected for predictive modeling analysis. Based on 4 1-wk measures at 1, 3, 6, and 9 months. LOD 0.008 mg/m^3^. Median 0.020 mg/m^3^; IQR 0.014, 0.027 mg/m^3^. Predictors included measures of continuous formaldehyde exposure, intermittent exposure, home characteristics, and air flow | Parent questionnaire at 1, 3, 6, 9, and 12 mos: Upper respiratory infections Lower respiratory infections Eczema wheezing episodes (frequency) At 12 mos, also includes shortness of breath, dyspnea, dry cough at night without cold Used to define lower respiratory infections with and without wheeze | Examined sex, older sibling, parental asthma, history, socioeconomic status (4 levels, based on parents’ occupation), prenatal and postnatal tobacco smoke exposure, dampness, breast feeding <3 mos, day care, pets in home | Exposure prediction model for high versus low (based on median): sensitivity 72.4% specificity 73.6%. Exposure prediction model by tertile: sensitivity 57.4% specificity 82.1%. Outcome examined as LRI versus no LRI, and as 3-level variable in multinominal logistic regression (LRI-with wheeze; LRI-no wheeze, no LRI) | N = 2,940 | Lower respiratory tract conditions in infants and toddlers; Medium; Did not test predictive model on separate sample (may overestimate sensitivity and specificity)
Rumchev et al. (2002); (Australia); Residences: children; (case-control); Related reference:; Rumchev et al. (2004) | Limited to ages 6–36 mos; recruitment process not described for cases or controls; cases from emergency room and controls (age matched) from area health department, representing the catchment area of the hospital | 8-hr samples, bedroom and living room, two seasons. Mean 0.030 and 0.28 and maximum 0.224 and 0.190 mg/m^3^, respectively, in bedroom and living room. | Emergency room discharge diagnosis of asthma, ages 6–36 mos. | Adjusted or considered age, allergies, family history of asthma, dust mites, relative humidity, temperature, atopy, environmental tobacco smoke, pets, air conditioning, use of gas appliances | Generalized estimating equation modeling for repeated measures | N = 88 cases, 104 controls | Lower respiratory tract conditionsn infants and toddlers; Medium; Recruitment process not described; uncertainty as to what is included within this case definition and length of time between emergency room visit and subsequent exposure measure.

#### Controlled Exposure Studies in People with Asthma

Table B-37 Evaluation of controlled acute exposure studies among people with asthma

Reference | Exposure assessment (details on exposure quality evaluation in Appendix B.3.1) | Outcome classification | Consideration of possible bias (randomized exposure order, blinding to exposure) | Consideration of likely confounding | Results presentation | Size | Confidence
Casset et al. (2006) | Formalin, 30 min, 0.032 (background) and 0.092 mg/m^3^, achieved concentrations analyzed. Includes allergy challenge. Nose clipped during exposure (mouth breathing) | Spirometry; FEV_1_, FEF_25-75_, PEF (protocol not mentioned) and bronchial challenge-airway reactivity test (PD_20_ FEV_1_ Der p1) (standard protocol) Testing pre- and every hour up to 6 hrs postexposure. | Mild asthma, ages 19–35 years, no respiratory infections for 2 wks; not in relevant allergy season or living with a pet if allergic. Random assignment to order of exposure (3 wks between experiments); double blinded | Within-person | Individual data values and t-tests | N = 19 | High; Randomized, double blinded, detailed data presentation; applies to mouth breathing
Ezratty et al. (2007) | Formalin, 60 min, 0 and 0.500 mg/m^3^, achieved concentrations analyzed. Includes allergy challenge | Spirometry; FVC, FEV_1_ (ECRHS protocol), and bronchial challenge-airway reactivity test (PD_15_ FEV_1_ grass) (standard protocol) Testing pre-and every hour up to 6 hrs postexposure. | Intermittent asthma (dyspnea < twice per week and night symptoms < twice per month with PEF > 80%), ages 18–44 years; not in allergy season. Random assignment to order of exposure (2 wks between experiments); double blinded. | Within-person | Individual data values and Wilcoxon sign rank test | N = 12 | High; Randomized, double blinded, detailed data presentation
Green et al. (1987) | Paraformaldehyde, 60 min, clean air and 3 ppm, achieved concentrations analyzed. | Spirometry; FVC, FEV_1,_ SGaw (ATS protocol), testing pre-and during exposure period, ≈15 min intervals. | Asthma (clinical history), no respiratory infection for 2 wks, age 19–35 years.; Random assignment to order of exposure; two 15-min exercise segments in 60-min exposure period; single blinded. | Within person | Group means and SE | N = 16 | Medium; Randomized, single blinded
Harving et al. (1990); Related Reference:; Harving et al. (1986) | Formalin, 90 min, filtered air (8), 0.120 and 0.850 mg/m^3^, achieved concentrations analyzed. | Spirometry; FEV_1_, R_aw_, SGaw (protocol not mentioned), testing pre- and near end of exposure period.; Bronchial challenge-airway reactivity test, immediately after exposure PEF by home peak flowmeter every 2 hrs after exposure and next morning | Asthma (substantial bronchial hyperreactivity to histamine), age 15–36 years.; Random assignment to exposure order (one per week); double blinded | Within-person | Group means and SD | N = 15 | High; Randomized, double blinded, detailed analysis
Krakowiak et al. (1998) | Formalin, 2 hrs, 0.5 mg/m^3^, achieved concentrations analyzed. | Spirometry FEV_1_ (testing 2 hrs pre- and immediately after, 5 hr, and 24 hr); PEF (testing at beginning of exposure, every hour for 12 hrs, 24 hrs after) | Formaldehyde-exposed workers with asthma, age 23–53 years. Order not randomized (1 wk between experiments); single blinded | Within person | Group means (bar graph) | N = 10 | Low; Not randomized, single blinding, SE or SD not reported
Sauder et al. (1987) | Paraformaldehyde, 3 hrs, clean air and 3 ppm (0 and 3.69 mg/m^3^), achieved concentrations analyzed. | Spirometry; FVC, FEV_1,_ SGaw (ATS protocol), testing at 0, 15, 30, 60, 120, 180 min during exposure. | Asthma (clinical history), no respiratory infection for 6 wks, age 26–40 years.; Order not randomized; clean air followed by formaldehyde (one week apart); blinding not specified | Within person | Grouped means and paired t-tests for most measures, individual FEV_1_ data | N = 9 | Low; Not randomized, blinding not specified
Sheppard et al. (1984) | Paraformaldehyde, 10 min, 0, 1, and 3 ppm (0, 1.23, and 3.69 mg/m^3^), achieved concentrations analyzed. | Spirometry; SGaw, testing before and 2 min after exposure. | Asthma (clinical history), age 18–37 years. Randomization of order not reported; two protocols (at rest and during exercise) ≥1 d apart; blinding not specified | Within person | Grouped means and SD and paired t-tests | N = 7 | Low; Randomization and blinding not specified
Witek et al. (1986); Witek et al. (1987) | Paraformaldehyde (with 2-propanol?), 40 min, 0 and 2 ppm (0 and 2.46 mg/m^3^) | Spirometry; FVC, FEV_1,_ R_aw_, testing during and at 10 and 30 min postexposure; PEFR assessed from 1 to 24 hrs post exposure. | Mild asthma (ATS definition), age 18–35 years. Random assignment to order of exposure; two protocols (at rest and during exercise); double blinded | Within person | Individual data values and paired t-test | N = 15 | High; Randomized, double blinded; nonparametric analysis could be preferred but individual data provided

### B.3.5 Respiratory Pathology

The details of the study evaluation approach methods are provided in Section 2.3.5 of the Toxicological Review. Within Tables B-38 (epidemiology studies in school and occupational settings), B-39 (controlled exposure studies in humans), and B-40 (animal studies) below documenting the results of the study evaluations for respiratory tract pathology, studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating.

#### Studies in Humans

##### Epidemiology Studies

Table B-38 Respiratory pathology study evaluations: epidemiology studies

Reference | Exposure measures and range | Outcome classification | Consideration of participant selection and comparability | Consideration of likely confounding | Analysis and completeness of results | Size/estimated power | Confidence
School Settings
Norback et al. (2000); (cross-sectional study) | Exposure measurements in 2 randomly selected classrooms at each school on 2 occasions; Measurements of respirable dust, CO_2_, temperature, humidity, formaldehyde (4-hr sample), airborne microorganisms, viable molds, and bacteria, NO_2_ (only in 1993); all staff assigned school mean concentration. Formaldehyde concentration: mean 0.0095 mg/m^3^; min-max of means, 0.003–0.016 mg/m^3^; provided citation for analysis; LOD 0.005 mg/m^3^ (Smedje et al., 1997) | Interview for symptoms, nasal lavage and acoustic rhinometry; use of both subjective and objective measures enabled evaluation of information bias | Primary school personnel at 12 of 18 randomly selected schools (out of 62) and with restriction to schools with classes 1–6 and no changes in ventilation or redecoration during study period (March 1993–March 1995). 234 current employees (84%) working 20 hr/wk or more. Excluded those on sick leave or otherwise off duty. High participation reduced likelihood of selection bias. | Multiple linear regression models adjusted for age, sex, smoking, atopy, and mean classroom temperature; Co-exposure: Nasal patency measures were inversely associated with dust, NO_2_, and Aspergillus. Elevations in nasal lavage biomarkers associated with NO_2_, Aspergillus, and yeast; correlation between indoor levels of pollutants or microbials not reported; correlated with ventilation? No indoor sources of combustion—NO_2_ levels higher in schools near traffic | Multiple linear regression models; reported regression coefficients and whether statistically significant (p <0.05); uncertainties in analysis: use of school-based mean concentration as unit of analysis | N = 234 individuals, but unit of analysis was school means, N = 12 | Low; Unknown correlation between co-exposures (dust, NO_2_, and Aspergillus) which also were inversely associated with nasal patency and biomarkers, potential confounding; some schools with mean < LOD; less robust analytic approach given unit of analysis
Occupational Settings
Ballarin et al. (1992); Prevalence study | Personal sampling; 8-hr TWA (NIOSH, 1977); Warehouse (N = 3), 0.39 ± 0.20 mg/m^3^, range 0.21–0.6 mg/m^3^; Shearing-press (N = 8), 0.1 ± 0.02 mg/m^3^, range 0.08–0.14 mg/m^3^; Sawmill (N = 1), 0.09 mg/m^3^; Inspirable wood dust: 0.11–0.69 mg/m^3^, 0.73 in sawmill; Uncertainty regarding concentrations during previous years. | Cytopathology analysis of nasal respiratory mucosa cells by 2 trained readers blinded to exposure status; scoring and classification analogous to Torjussen et al. (1979) and (Edling et al., 1988); most severe score present assigned. | Details of participant recruitment not described. Nonsmokers in plywood factory (N = 15) compared to nonsmoking university or hospital clerks (N = 15) matched by age and sex. Excluded heavy drinkers. Potential confounding by wood dust | Addressed potential confounding by age and sex through matching and smoking and heavy alcohol use by exclusion. | Mean histological scores in exposed and referent compared using Mann-Whitney U test and frequency by classification using chi-square test | N = 15 exposed/unexposed pairs | Medium; Uncertainty regarding exposure levels during previous years. Small sample size increases potential for unreliable results. Inclusion only of current workers raises possibility of healthy worker survival effect due to irritation effects.
Berke (1987); Cross-sectional study | Exposure measurements since the mid 1970s using personal monitoring (monitoring protocol not described). Group 1 ranging from 0.02–1.3 ppm. Group 2 plant 0.05–2.0 ppm | Clinical exam and nasal cytology by pathologist blind to exposure or clinical status. System for classifying atypical and typical metaplasia not defined. | 52 volunteers from 3 paper plants (currently employed, participation 95% of available exposed) Group 1&2: 42 exposed, Group 3: 10 referent workers. Group 3: 28 additional referent white-collar employees (36% atypical squamous metaplasia in this group)—not clearly representative | Mean age in exposed higher than employee referent group, comparable to additional white-collar referent group. Smoking prevalence 60% in Groups 1, 2, and 3; 20% in white-collar referent. Statistical analysis excluding smokers | Exposed (Groups 1 and 2) compared to referent (Groups 3 and 4); chi-square test with adjustment for age and smoking; analysis of combined groups not appropriate (exposures different and very different demographic characteristics) | N = 42 exposed, 10 employee referents, 28 whitecollar referents | Not Informative; Methods were not well described. Comparisons of dissimilar groups. Nonstandard outcome definition and analyses that cannot be interpreted. Inclusion of only current workers and long duration of employment (mean >15 years) raises possibility of healthy worker survival effect
Boysen et al. (1990); Cross-sectional, study | Formaldehyde monitoring conducted after 1980. Before 1980, exposure assigned by plant health officer with knowledge of the production process, recent measurements, and worker sensations. Range of formaldehyde 0.5 ppm to >2 ppm (0.62–2.5 mg/m^3^); no measurements in referent; however, exposure contrast likely adequate. | Slides evaluated by two authors blinded to clinical or occupational status. Histology: Scoring and classification of histologic samples per variation of Torjussen et al. (1979) protocol.; Rhinoscopy: Scoring according to Boysen and Solberg (1982) | 37/74 volunteers from a chemical company producing formaldehyde (50% of exposed workforce). Referents: 37 age matched subjects without overt nasal disease (office staff, hospital laboratory personnel, and EN&T outpatients). Use of referent group with different occupations results in less similar comparison groups. | Exposed and referent comparable for age, smoking, or previous nasal disease. | Comparison of histological results between exposed and referent groups using Wilcoxon rank sum test, evaluated associations with age, smoking, intensity and duration of exposure; comparison of rhinoscopical results using chi-square test | N = 37 exposed, 37 referents | Medium; Inclusion only of current workers and long duration of employment raises possibility of healthy worker survival effect due to irritation effects.
Edling et al. (1987a, 1988); Prevalence Study; Related studies:; Odkvist et al. (1985) | Past TWA formaldehyde measurements by plant industrial hygienists sporadically between 1975 and 1983. Levels of formaldehyde in air ranged from 0.1–1.1 mg/m^3^, with peaks up to 5 mg/m^3^. No measurements available before 1975, but estimated levels higher during the 1960s and early 1970s. No measurements in referent; however, exposure contrast likely adequate. | Rhinoscopy: Nasal mucosa histological grading by pathologist blinded to exposure using Torjussen et al. (1979) grading system | 75 of 104 exposed male factory workers from 3 plants (72% of eligible). Referents: 25 men with similar age and no known industrial exposures to formaldehyde; source of referent group not described. Evaluated characteristics of nonparticipants at 1 plant, age and exposure time similar, % with symptoms higher in nonparticipants, % smokers lower. | Exposed mean age: 38 years; 35% smokers. Referent mean age: 35 years, 48% smokers. Histological score was higher among exposed smokers compared to ex-smokers and nonsmokers; possible confounder | Exposed groups compared to referent group using Wilcoxon rank sum test, no adjustment for age or smoking | N = 75 exposed, 25 referents | Medium; Inclusion of only current workers and long duration of employment (mean 10.5 years) and high prevalence of symptoms raises possibility of healthy worker survival effect due to irritation effects. Potential for confounding by smoking.
Holmström and Wilhelmsson (1988); Holmstrom et al. (1989c); Cross-sectional study | Personal sampling in breathing zone for 1–2 hrs in 1985. Chemical Plant: 0.05–0.5 mg/m^3^, mean 0.26 [SD 0.17 mg/m^3^]. Furniture Factory: 0.2–0.3 mg/m^3^, mean 0.25 [SD 0.05 mg/m^3^]. Referent 0.09 mg/m^3^ formaldehyde. Total dust and respirable dust also measured. Uncertainty regarding measured exposure levels and levels in etiologically relevant period. | Nasal symptoms questionnaire, nasal volume flow rate using rhinomanometry; mucociliary clearance using green dye to measure time for spot to reach rhinopharynx. Histological changes in nasal mucosa graded by a pathologist blind to exposure according to Torjussen et al. (1979) | Nasal specimens in 62 of 70 formaldehyde exposed, 89 of 100 formaldehyde/wood dust exposed, and 32 of 36 referents. Excluded subjects with upper airway infections; Apparent high participation and outcome assessment blinded to exposure status reduced likelihood of selection bias. Use of referent group with different occupations results in less similar comparison groups. | Formaldehyde exposed were than formaldehyde-dust exposed or referent; smoking status higher in exposed; higher % male in exposed groups. Duration of exposure and smoking status were not correlated with histology score, therefore confounding not a concern | Compared exposure groups using 2-tailed t-test for symptoms, nasal flow rate, and histology, and chi-square test for mucociliary clearance | N = 62 of 70 Group 1, N = 89 of 100 Group 2, N = 32 of 36 Referent | Medium; Inclusion of only current workers and long duration of employment raises possibility of healthy worker survival effect due to irritation effects
Löfstedt et al. (2011b); Cross-sectional Study; Related study: Westberg et al. (2005) (exposure methods) | Personal sampling over a single 8-hr shift. Formaldehyde concentration, mean (SD), range: 0.051 (0.049) mg/m^3^, 0.013–0.190 mg/m^3^; 71.4% of exposed <LOD for formaldehyde (<0.02 mg/m^3^). | Nasal symptoms and signs; questionnaire; examination by rhinologist blind to exposure status | 43 exposed employees at 3 brass foundries producing cores using Hot Box method (90%) Referent: 82 assembly workers and storage workers with no chemical exposure (98%); high participation reduced likelihood of selection bias. Use of referent workers from same companies increased similarities between groups. Possible healthy worker survival selection because of inclusion only of current workers and irritant exposures, but authors said there was no evidence. | Evaluated impacts of confounding by exclusion of smokers, females, or asthmatic and allergic subjects from analysis. Other exposures also associated with nasal signs: isocyanic acid (ICA) and methyl isocyanate (MIC) and dust; correlations between co-exposures ranged between −0.08 and 0.65 (except ICA and MIC, r = 0.92); analyses using metric for combined exposure to multiple irritants. | Logistic regression, single-pollutant analyses, OR (95% CI); cut-point for categories of formaldehyde exposed was LOD. | N = 69 unexposed, 30 low and 12 high exposure | Low; Formaldehyde levels among exposed were low (30 of 43 exposed at <LOD). Possible confounding of formaldehyde associations by ICA or MCA, but correlation for pollutant pairs was not reported.

##### Controlled Exposure Studies in Humans

Table B-39 Respiratory pathology study evaluations: controlled exposure studies in humans

Reference | Exposure measures and range (exposure quality evaluations in B.3.1) | Outcome classification | Consideration of participant selection and comparability | Consideration of likely confounding | Analysis and completeness of results | Size/estimated power | Confidence
Andersen and Lundqvist from Andersen and Molhave (1983)^a^ | Paraformaldehyde. Dynamic chamber; analytic concentrations; clean air followed by 0.3, 0.5, 1.0, and 2.0 mg/m^3^ formaldehyde.; Adequate | Nasal airflow resistance and nasal mucociliary flow | Subjects assigned to four groups, each group with four different exposures over four consecutive days, order decided by Latin square design. Clean air exposure order not randomized. Blinding not described | Within-person comparison | Results presented with statistical analyses | N = 16 | Medium; Clean air exposure order not randomized. Blinding not described
Falk et al. (1994) | Formalin exposure; analytic concentrations, mean: Group 1: 0.021, 0.028, 0.073, 0.174; Group 2: 0.023, 0.029, 0.067, 0.127; Deficient | Nasal mucosa swelling measured using rhinostereometry (summary of changes for both turbinates) | Double blind exposures, exposure-order stochastically distributed and separated by 2 d. | Within-person comparison | Results presented in graphs | N = 6–7 per group | Medium; Formalin source; small group size
Pazdrak et al. (1993) | Test article characterization and exposure generation method not described; clean air followed by 0.5 mg/m^3^ formaldehyde; Deficient | Stage 1 evaluation of symptoms, morphological changes, and biochemical changes in nasal washings. Stage 2 clinical comparison of nasal mucosa by group. | Two-stage, single-blind examination with nonrandom order of exposure assignment. | Within-person comparison | Results presented with statistical analyses | N = 8–11 per group | Low; Formalin source of exposure; nonrandom order of exposure assignment; investigators not blinded. Small group size.

a At the request of EPA’s Office of Chemical Safety and Pollution Prevention, EPA’s Human Studies Review Board review of four intentional exposure studies for potential use in assessing acute formaldehyde inhalation determined the ethical conduct of this study to be adequate.

#### Studies in Animals

Animal studies in Table B-40 are grouped by exposure duration, and then organized alphabetically by first author. Specific study details (or lack thereof) that highlight a limitation or uncertainty in answering each of the domain criteria are noted in the table cells. For those identified as having a substantial limitation likely to influence the study results (major limitations), the relevant study details are bolded. Italics are used to highlight other limitations not viewed as substantial in the context of respiratory tract pathology (minor limitations). A ‘Good’ domain rating is denoted by ‘++’; an ‘Adequate’ rating by ‘+’; and a ‘Deficient’ rating by gray shading. See Appendix B.3.6 for documentation of evaluations on studies of cellular proliferation or mucociliary function in the respiratory tract.

Table B-40 Evaluation of controlled inhalation exposure studies examining respiratory pathology in animals

Reference and species | Exposure quality^a^ (details in Appendix B.3.1) | Test subjects | Study design | Endpoint evaluation | Data considerations and statistics | Confidence classification
Respiratory Pathology—Chronic
(Appelman et al., 1988); Rat | ++ | +; Small N (N=10) | ++ | +; Lesion severity provided for 13-wk but not 52-wk sacrifice | ++ | Medium; [small N; limited reporting of lesion severity]
(Dalbey, 1982); Hamster | ++ | ++ | ++; Note: single concentration study | +; Lesion severities NR | ++ | Medium; [failure to report lesion severities]
(Holmstrom et al., 1989b); Rat | ++; Note: high concentration exposure (15.3 mg/m^3^-d) | +; Small N (N=16/group) | ++; Note: single concentration study | Lesion severities NR; nonstandardized histological characterization makes interpretation of effect difficult | Incidence of metaplasia and dysplasia reported together | Not Informative; [small N; failure to report lesion severities; incidence of metaplasia and dysplasia reported together]
(Kamata et al., 1997); Rat | +; Formalin; methanol concentration was reported and a methanol control was used. | +; Small number of animals for interim sacrifices (N = 5) | ++ | +; Lesion severities NR; prevalence of neoplastic lesions complicates assessment of nonneoplastic lesions | ++ | Medium; [formalin; small N for interim sacrifices; failure to report lesion severities]
(Kerns et al., 1983); Mouse; See also (Swenberg et al., 1980a; Swenberg et al., 1980b; Battelle, 1982) | ++ | +; Survival to 18 mos was <33% in all groups (N>25) | ++; Note: data from this study based on a GLP study (Battelle, 1982) | Lesion severities NR; incidence NR; only three nasal sections (II, III, and V) evaluated | ++ | Medium; [limited sampling, high mortality, and failure to report lesion incidence and severities]
(Kerns et al., 1983); Rat; See also (Swenberg et al., 1980a; Swenberg et al., 1980b; Battelle, 1982) | ++ | +; Transient viral infection at wks 52-53 was considered unlikely to influence study outcome because of its short course | ++; Note: data from this study based on aGLP study (Battelle, 1982) | ++; Note: incidence and severity data by nasal section extracted from the full GLP report | ++ | High; [Note: transient viral infection]
(Monticello et et al., 1996); Rat | ++ | ++ | ++ | Lesion severities NR; lesion incidence NR | +; Insufficient data to verify magnitude of concentration-response | Low; [Failure to report lesion incidence and severities; insufficient data to verity magnitude of concentration-response]
(Sellakumar et al., 1985); Rat; see also (Albert et al., 1982) | +; Formaldehyde was generated by heating a slurry of paraformaldehyde in paraffin oil (kerosene), which could cause co-exposure to paraffin oil. [Note: high concentration exposure (18.2 mg/m^3^-d)] | ++ | ++; Note: single concentration study | +; Lesion severities NR | ++ | Medium; [Likely co-exposure to paraffin oil (kerosene); testing at a single high concentration; failure to report lesion severities]
(Woutersen et al., 1989); Rat | ++ | ++ | ++ | +; Lesion severities NR; significant incidence of lesions in controls | ++; Statistical analyses of lesions NR | High; [Failure to report lesion severities]
Respiratory Pathology—Subchronic
(Andersen et al., 2010); Rat | ++ | +; small N (N = 8) | ++ | ++ | +; Data for levels III-VNR; statistical analyses of lesions NR | Medium; [Small N; data for levels III-VNR]
(Arican et al., et al., 2009); Rat | Analytical method and concentrations NR | ++ | ++; Note: single concentration study | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Failure to report analytical method and analytical concentrations; failure to report lesion incidence and severities]
(Bansal et al., 2011); Rabbit | Formalin; Analytical method concentrations NR | Small N (N = 2 controls and N = 6 exposed) | Continuous exposure (24 hrs/d) | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Deficient exposure quality; Small N; failure to report lesion incidence and severities]
(Casanova et al., 1994); Rat | ++ | Small N (N = 3) | ++ | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Small N; failure to report lesion incidence and severities]
(Coon et al., 1970); Dog | ++ | Small N (N = 2) | Continuous exposure (22 hrs/d) Note: single concentration study | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Small N; single concentration tested; failure to report lesion incidence and severities]
(Coon et al., 1970); Guinea pig | ++ | ++ | Continuous exposure (22 hrs/d) Note: single concentration study | Lesion severity NR; lesion incidence NR | +; + Qualitative descriptions only | Not Informative; [Continuous (high) exposure; failure to report lesion incidence and severities]
(Coon et al., 1970); Monkey | ++ | Small N (N = 3) | Continuous exposure (22 hrs/d) Note: single concentration study | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Small N; continuous (high) exposure; failure to report lesion incidence and severities]
(Coon et al., 1970); Rabbit | ++ | Small N (N = 3) | Continuous exposure (22 hrs/d) Note: single concentration study | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Small N; continuous (high) exposure; failure to report lesion incidence and severities]
(Coon et al., 1970); Rat | ++ | ++ | Continuous exposure (22 hrs/d) Note: single concentration study | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not informative; [Continuous (high) exposure; failure to report lesion incidence and severities]
(Feron et al., 1988); Rat | ++; Note: exposure in the high concentration group was excessive (24.4 mg/m^3^-d) | ++ | ++ | +; No quantitative interim sacrifice data to inform lesions immediately after exposure | ++; Note: recovery period data informs persistence of lesions | High; [Note: only tested high formaldehyde levels]
(Horton et al., 1963); Mouse | +; Analytical concentrations NR Note: extremely high concentration exposure (200 mg/m^3^-d) | ++ | +; Early mortality in high exposure group by 11^th^ d of exposure | Nose was not examined; lesion severity NR Note: lesions are of questionable adversity | ++ | Low; [Analytical concentrations NR; early mortality in the high concentration group, which had an extremely high concentration; nose was not examined; failure to report lesion severity]
(Maronpot et al., 1986) Mouse | +; Formalin; methanol concentration was not reported and a methanol control was not used. [Note: high concentration exposure (49.2 mg/m^3^)] | +; Small N (N=10) | ++ | ++ | ++ | Medium; [Formalin; small N]
(Rusch et al., 1983); Rat | ++; Note: concentrations tested were very low (0.23-3.6 mg/m^3^-d), and unlikely to elicit a response | ++ | ++ | +; Lesion severity NR | incidence of squamous metaplasia and hyperplasia reported together; data reported for only one nasal section | Medium; [Failure to report lesion severity; incidence of squamous metaplasia and hyperplasia reported together; data reported for only one nasal section]
(Rusch et al., 1983); Monkey | ++; Note: concentrations tested were very low (0.23-3.6 mg/m^3^-d), and unlikely to elicit a response | ++ | ++ | +; Lesion severity NR | Incidence of squamous metaplasia and hyperplasia reported together; data reported for only one nasal section | Medium; [Failure to report lesion severities; incidence of squamous metaplasia and hyperplasia reported together; data reported for only one nasal section]
(Rusch et al., 1983); Hamster | ++; Note: concentrations tested were very low (0.23-3.6 mg/m^3^-d), and unlikely to elicit a response | ++ | +; Limited study design: only endpoint evaluated was squamous metaplasia | ++ | Specific incidence data NR, so lack of effect could not be verified | Medium; [Specific incidence data NR; only squamous metaplasia was evaluated]
(Wilmer et al., 1989); Rat | +; Analytical concentrations NR | ++ | ++ | +; Lesion severity NR | ++ | Medium; [Analytical concentrations NR; failure to report lesion severities]
(Woutersen et al., 1987); Rat | ++; Note: high concentration exposure (24.4 mg/m^3^-d) | ++ | ++ | ++ | ++ | High; [Note: the high concentration level was excessive]
(Zwart et al., 1988); Rat | ++ | ++ | ++ | +; Lesion severity NR | +; Lesion incidence incompletely reported | Medium; [Failure to completely report lesion incidence; severity NR]
Respiratory Pathology—Short-term
(Andersen et al., 2008); Rat | +; ≈30% variations in chamber concentrations | +; Small N (N = 8) | ++ | ++ | +; Statistical analyses of lesions NR | Medium; [Small N; variation in chamber concentrations]
(Bhalla et al., 1991); Rat | Analytical method and concentrations NR | +; Small N (N = 6) | + +; Note: single concentration study | Lesion severity NR; lesion incidence NR | ++ | Not Informative; [Failure to report analytical method and FA concentrations; small N, failure to report lesion incidence and severities]
(Buckley et al., 1984); Mouse | +; Formalin; methanol concentration was not reported and a methanol control was not used | ++ | ++; Note: single concentration study | Lesion incidence NR | +; Statistical analyses of lesions NR | Low; [Formalin; failure to report lesion incidence]
(Cassee and Feron, 1994); Rat | ++ | ++ | ++; Note: single concentration study | ++ | Statistical analyses of lesions NR; Incidence and severity of hyperplasia and metaplasia reported together | Medium; [Incidence and severities of hyperplasia and metaplasia were reported together]
(Cassee et al., 1996b); Rat | ++ | +; Small N (N=6) | ++ | ++ | Statistical analyses of lesions NR;; Data NR for 7.9 mg/m^3^ group | Medium; [Small N, failure to report data for the 7.0 mg/m^3^ group]
(Chang et al., 1983); Rat | ++ | Sample size N unclear | Note: single concentration study; this study measured reflex bradypnea | Lesion severity NR; lesion incidence NR | +; Statistical analyses of lesions NR | Low; [Sample size unclear, failure to report lesion incidence and severity]
(Chang et al., 1983); Mouse | ++ | Sample size N unclear | Note: single concentration study; this study measured reflex bradypnea | Lesion severity NR; lesion incidence NR | +; Statistical analyses of lesions NR | Low; [Sample size unclear, failure to report lesion incidence and severity]
(Ionescu et al., 1978); Rabbit | Test article characterization NR; analytical concentrations NR; formaldehyde generation method NR | Test subject strain and number NR | ++; Note: single concentration study | Lesion severity NR; lesion incidence NR | ++ | Not Informative; [Analytical concentrations NR; test article characterization NR; FA generation method NR; test subject strain and number NR; failure to report lesion incidence and severity]
(Kamata et al., 1996b); Rat | +; Formalin; no methanol control or concentration was reported. [Note: high concentration exposure; (179.1 mg/m^3^)] | +; Small N (N = 5) for histo-pathology | ++ | Lesion severity NR; lesion incidence NR | +; Statistical analyses of lesions NR | Low; [Formalin; small N for histopathology; failure to report lesion incidence and severities]
(Kuper et al., 2011); Rat | +; Appears to be freshly made formalin; although formaldehyde generation method NR | +; Small N (N = 8) | ++; Note: GLP-compliant study | ++ | ++ | Medium; [Small N; unclear test article]
(Kuper et al., 2011); Mouse | +; Appears to be freshly made formalin; although formaldehyde generation method NR | +; Small N (N = 6) | ++; Note: GLP-compliant study | ++ | ++ | Medium; [Small N; unclear test article]
(Lima et al., 2015); Rat | Test article characterization NR; concentrations NR- [Note: likely high levels] | +; Small N (N = 7); males only | Short (20 min × 3) daily exposures; controls did not appear to be chamber exposed.; Note: 5 d exposure | Lesion severity NR; lesion incidence (nonmorphometric analyses) NR; Note: randomized, but blinding NR | +; Statistical analyses of lesions NR | Not Informative; [Failure to characterize the test article and report levels; short periodicity; lesion data NR]
(Ohtsuka et al., 1997); Rat | Test article characterization NR; concentrations NR- [Note: likely high levels] | Small N (N=5 total, but only N = 2 nasal and N = 3 other levels examined); males only | +; Short (3 hr) daily exposure for 2 wk (5 d/wk) with no longterm follow up | Lesion severity NR; lesion incidence NR | +; Qualitative descriptions only | Not Informative; [Failure to characterize the test article and report levels; small N; lesion data NR]
(Monteiro-Riviere and Pope, 1986); Rat | ++ | +; Small N (N = 5; note: only 3/ treated group examined in “detail”) | ++ | Lesion severity NR; lesion incidence NR | +; Statistical analyses of lesions NR | Medium; [Small N; lesion incidence and severity NR]
(Monticello et al., 1989); Monkey | +; Analytical concentrations NR | ++ | ++; Note: single concentration study | Lesion severity NR; lesion incidence NR | ++ | Medium; [Analytical concentrations NR; lesion incidence and severity NR]
(Murta et al., 2016); Rat | Test article characterization NR; concentrations NR- [Note: likely high levels] | +; Small N (N = 7); males only | Short (20 min × 3) daily exposures note: 5 d exposure | Lesion severity NR; lesion incidence (nonmorphometric analyses) NR; Note: randomized, but blinding NR | +; Statistical analyses of lesions NR | Not Informative; [Failure to characterize the test article and report levels; short periodicity; lesion data NR]
(Morgan et al., 2017); Mouse | +; Analytic concentrations NR | ++; Note: “randomly assigned”; Males only; ≈25 mice/ group; genetically modified (Trp53+/-) | ++; Note: 8 wk exposure duration with 32 wk follow up was not a notable issue for these outcomes as numerous lesions found | Blinding NR; only 3 nasal sections evaluated (and 1 larynx) | +; Statistical analyses of lesions NR | Medium; [limited sampling and minor reporting limitations]
(Reuzel et al., 1990); Rat | ++ | ++ | ++ | ++ | +; Statistical analyses of lesions NR | High
(Schreiber et al., 1979); Hamster | Test article characterization NR; analytical concentrations NR; formaldehyde generation method NR; Note: high concentration exposure (307.5 mg/m^3^) | +; Small N (N = 3 to 5) | ++; Note: single; concentration study | Lesion severity NR; lesion incidence NR | +; Statistical analyses of lesions NR | Not Informative; [Failure to characterize the test article, describe the generation method, and report analytical concentrations; failure to report lesion incidence and severities]
(Speit et al., 2011b); Rat | +; Formalin; methanol concentration was not reported and a methanol control was not used | +; Small N (N = 6) | ++ | ++ | ++ | Medium; [Small N; formalin]
(Wilmer et al., 1987); Rat | +; Analytical concentrations NR | ++ | ++ | Lesion severity NR; lesion incidence NR | ++; Note: intermittent versus continuous exposures compared | Medium; [Analytical concentrations NR; failure to report lesion incidence and severities]
(Yorgancilar et al., 2012); Rat | Test article characterization NR; analytical concentrations NR; formaldehyde generation method NR | +; Small N (N = 8) | ++; Note: single concentration study | Lesion severity NR; lesion incidence NR | +; Statistical analyses of lesions NR | Not Informative; [Failure to characterize test article; failure to report analytical concentrations and generation method; small N; failure to report lesion incidence and severities]

NR = not reported; N/A = not applicable.

a Although some notes on exposure levels are included, considerations and interpretations related to the tested exposure levels are discussed as part of the evidence synthesis in the Toxicological Review.

### B.3.6 Mechanistic Information Related to Inflammation and Immune Effects

As described in Section 2.3.6 of the Toxicological Review, this broad mechanistic evaluation encompassed studies relating to multiple noncancer health outcomes as well as cancer. It includes the evaluation of studies identified through the searches documented in Appendix B.2.6 as well as animal studies of hypersensitivity responses, and studies of cell proliferation and mucociliary function, some of which were identified through other health effect-specific searches. Details of the study evaluation approach methods are provided in Section 2.3.6 of the Toxicological Review. The approach to documentation in Table B-41 to Table B-48 highlights important study details regarding the design of each experiment and summarizes the results. The utility of each set of study findings to evidence synthesis and integration judgments is summarized, with supporting documentation highlighting the study details leading to each judgment. The documentation of the review of human studies with both mechanistic and apical health effect evidence that were evaluated in other sections is based on those more detailed health effect evaluations. Studies on the implications of altered endogenous formaldehyde levels are not extracted into the tables below, although there may be some contextual discussion (e.g., to inform potential susceptibility) in the Toxicological Review. The study evaluation tables are first organized according to mechanistic effect type, and then within each effect type into observational and controlled exposure studies organized alphabetically. Specific study details (or lack thereof) that highlight a limitation or uncertainty in answering each of the domain criteria are noted in the table cells. For those identified as having a substantial limitation likely to influence the study results (major limitations), the relevant study details are bolded. Italics are used to highlight other limitations not viewed as substantial in the context of respiratory tract pathology endpoints (minor limitations).

#### Evaluation of Mechanistic Evidence Related to Changes in the Upper Respiratory Tract (URT)

##### Cell Proliferation and Mucociliary Function Studies in Animals

Cell proliferation and mucociliary function animal studies in Table B-41 were evaluated using the criteria applied to respiratory tract pathology studies (see Appendix B.3.5).

Table B-41 Evaluation of controlled inhalation exposure studies examining cell proliferation and mucociliary function in animals

Experimental feature categories
Reference and species | [underlined: Exposure quality]^a^ (details in Appendix B.3.1) | [underlined: Test subjects] | [underlined: Study design] | [underlined: Endpoint evaluation] | [underlined: Data considerations & statistics] | [underlined: Confidence classification]
Cell Proliferation
(Andersen et al., 2008); Rat | +; ≈30% variations in atmospheres | ++ | ++ | ++ | ++ | High
(Andersen et al., 2010); Rat | ++ | +; Variable sample size (N = 1 to 8) | ++ | ++ | ++ | High
(Casanova et al., 1994); Rat | ++ | ++ | Relevance of exposure scenario unclear (Note: nasal regions selected for analysis may not be relevant to humans) | ++ | ++ | Medium
(Cassee and Feron, 1994); Rat | ++ | +; Number of cells analyzed NR | ++; Note: single concentration study | ++ | ++; Qualitative data only | Medium
(Cassee et al., 1994b); Rat | ++ | +; Small N (N = 3 to 5) | ++ | +; Data for 7.9 mg/m^3^ NR | ++ | High
(Chang et al., 1983); Rat | ++ | +; Variable sample size (N = 4 to 9) | Unclear description of study design; Note: single concentration study | ++ | ++ | Medium
(Chang et al., 1983); Mouse | ++ | +; Variable sample size (N = 4 to 10) | Unclear description of study design; Note: single concentration study | ++ | ++ | Medium
(Kuper et al., 2011); Rat | ++; Formaldehyde generation method NR | ++ | ++; Note: GLP-compliant study | ++ | ++ | High
(Kuper et al., 2011); Mouse | ++; Formaldehyde generation method NR | ++ | ++; Note: GLP-compliant study | ++ | ++ | High
(Meng et al., 2010); Rat | +; Analytical concentrations NR | ++ | ++ | ++ | ++ | High
(Monticello et al., 1991); Rat | ++ | +; Variable sample size (N = 4 to 6) | ++ | ++ | ++ | High
(Monticello et al., 1989); Monkey | +; Analytical concentrations NR | ++ | +; Note: single concentration study | +; Qualitative data only for nasal region | ++ | Medium
(Monticello et al., 1996); Rat | ++ | +; Variable sample size (N = 3 to 8) | +; Nonstandard selection of nasal regions; Note: regions may not be relevant to humans | ++ | +; Statistical analyses of cell proliferation NR | Medium
(Reuzel et al., 1990); Rat | ++ | ++ | ++ | ++ | + + | High
(Roemer et al., 1993); Rat | ++ | ++ | ++ | ++ | ++ | High
(Speit et al., 2011b); Rat | +; Formalin exposure; no methanol controls and concentration NR | ++ | ++ | ++ | ++ | Medium
(Wilmer et al., 1987); Rat | +; Analytical concentrations NR | Small and variable sample size (N = 1 to 3) | ++ | ++ | ++ | Medium
(Wilmer et al., 1989); Rat | +; Analytical concentrations NR | ++ | ++ | ++ | ++ | High
(Feron et al., 1987); Rat | ++; Note: high; concentration exposure (24.4 mg/m^3^-d) | Small N (N=2) | ++ | ++ | +; Statistical analyses of cell proliferation NR | Medium
(Zwart et al., 1988); Rat | ++ | ++ | ++ | ++ | +; Cell proliferation data not readily accessible from graphic form | High
Mucociliary Function
(Fló-Neyret et al., 2001); Frog | Not an inhalation study. Exposure based on immersion into formaldehyde solution (i.e., formalin) | +; frogs | Ex vivo amphibian study; experiments carried out three days after sacrifice; mucus removed from palate during preparation and returned to palate for testing | ++ | ++ | Not Informative
(Morgan et al., 1984); Frog | +; Analytical concentrations within 20% of nominal | +; frogs | Ex vivo amphibian study; method of sacrifice (anesthesia) and palate harvest NR | +; Inter-animal variation observed at several concentrations | ++ | Low
(Morgan et al., 1986a); Rat | ++ | ++ | ++; Note: mucociliary function assessed using dissected nasal cavities | ++ | +; Statistical analyses of mucociliary function data NR | High
(Morgan et al., 1986c); Rat | ++ | ++ | ++; Note: mucociliary function assessed using dissected nasal cavities | ++ | +; Statistical analyses of mucociliary function data NR | High

NR = not reported; N/A = not applicable.

a Although some notes on exposure levels are included, considerations and interpretations related to the tested exposure levels are discussed as part of the evidence synthesis in the Toxicological Review.

##### Other Changes in the Upper Respiratory Tract

Table B-42 URT-specific structural modification, sensory nerve-related changes, or immune and inflammationrelated changes

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
[underlined: Observational Epidemiology Studies]
(Lyapina et al., 2004) | Symptomatic and nonsymptomatic human workers with carbamideFA glue (n = 29) | Exposed workers: 0.87 ± 0.39 mg/m^3^ (n = 21 nonexposed); duration mean: 12.7 ± 9.6 years | Assessment of chronic URT inflammation | Statistically significant increase in subjective symptoms and objective clinical findings of chronic, URT inflammation (e.g., hypertrophy/atrophy of mucus membranes; rhinitis) and decreased neutrophil function (but N/C in leukocyte cell counts) in workers; symptomatic workers exhibited decreased resistance to infections (increased frequency, duration) | High or Medium Confidence [mixture exposure]
(Bono et al., 2016) | Human plastic laminate workers (n = 50) and office personnel controls (n = 45); males only | Controls (mean ± SE and range): 0.035 ± 0.0034 (0.016–0.11) mg/m^3^; Workers: 0.211 ± 0.015 (0.049–0.444); duration unclear | Nasal epithelial ROS (M_1_dG adducts; a marker of oxidative stress and lipid peroxidation) | Increased adducts with increasing formaldehyde exposure (p trend= 0.002), with statistically significant increases at > 0.066 mg/m^3^ (i.e., <0.025 mg/m^3^ = 47.6; 0.025–0.066 mg/m^3^ = 59.2; and >0.066 mg/m^3^ = 105.5 adducts) | High or Medium Confidence [unknown duration]
(Holmström and Wilhelmsson, 1988); (note: mucociliary function data below) | Two exposed groups (n = 170 total; ≈90% male); 70 formaldehyde production workers; 100 workers exposed to wood dust and formaldehyde at five furniture factories; Referent: (n=36; ≈55% male) from government, with no history of formaldehyde or wood dust exposure | Exposed workers: chemical plant: 0.05–0.5 mg/m^3^, mean 0.26 [SD 0.17 mg/m^3^]. Furniture factory: 0.2–0.3 mg/m^3^, mean 0.25 [SD 0.05 mg/m^3^]. Referent mean 0.09 mg/m^3^ (based on 4 measurements in 4 seasons); duration of employment >10 years | Symptoms of URT inflammation Histopathology scores | Symptoms of nasal obstruction and nasal watery discharge more frequent in exposed (p <0.05). When divided into subgroups based on exposure time, there were no signs of increasing nasal restrictivity after employment >5 years.; Formaldehyde-only nasal specimens mean histological score: 2.16 (range 0–4) (p <0.05) compared to referent group 1.56 (range 0–4); while formaldehyde-dust group had mean score 2.07 (range 0–6) (p >0.05).; No correlation observed between smoking habits and biopsy score, nor was a correlation found between the duration of exposure and any histological changes. | Low Confidence [Inclusion of only current workers and long duration of employment raises possibility of healthy worker survival effect due to irritation effects; referent group not well matched (different type of work activity; undersampled males); crude measures of effect
(Norback et al., 2000) | Primary school personnel in Sweden (n = 234) | 0.003–0.016 (mean=0.0095) mg/m^3^; duration unclear (working at least 20 hr/wk; assumed length mos or more) | Assessment of acoustic rhinometry and factors in nasal lavage | Formaldehyde was significantly associated with multiple measures of nasal obstruction.; Formaldehyde was positively associated with biomarkers for eosinophils (eosinophil cationic protein; lysozyme); N/C in a neutrophil marker (myeloperoxidase) or albumin | Low Confidence [mixture exposure (formaldehyde was independently associated with these changes, but so were NO_2_ and Aspergillis)-did not evaluate confounding; some school measures below the limit of detection]
(Priha et al., 2004) | Human MDF board workers (n = 22) versus wood dust (n = 23) and nonexposed (n = 15) | 0.19± 0.11 mg/m^3^ (MDF board) versus 0.11 ± 0.08 mg/m^3^ (note: VOCs 3-fold higher in MDF than wood); pre- and post-8-hr workshift | Nasal lavage cell and cytokine counts | N/C in cell counts Increased postshift total protein vs. unexposed controls; Increased post- vs. preshift NO (nitrite) in wood and MDF workers Decreased post- vs. preshift TNFα in wood workers | Low Confidence [short duration; minimal exposure differential; role of VOCs not accounted for]; NOTE: ACUTE (8 hr; cross-shift)
[underlined: Controlled-Exposure Studies in Humans or Primary Human Cells]
(Pazdrak et al., 1993) | Human occupationally exposed (n = 10 males and females) with positive reaction to FA: “allergic”; 11 “nonallergic” control males | Formalin (assumed: test article NR): 0.5 mg/m^3^ for 2 hr with follow-up out to 16–18 hr | Nasal lavage cell and protein counts Note: changes were associated with scoring measures of nasal symptoms (e.g., sneezing; edema) | Increased number of eosinophils, albumin, and total protein; N/C basophils; Increased proportion of eosinophils and decreased proportion of epithelial cells; N/C in proportion of basophils, neutrophils, or mononuclear cells (i.e., lymphocytes and monocytes); Effects max 10 min after exposure and declining, but still significant, at 16–18 hr; effects observed regardless of “allergy” | Low Confidence [formalin; short duration; somewhat small sample size; lack of investigator blinding (nonissue for automated albumin measures)]; NOTE: ACUTE; authors noted albumin changes may indicate increased mucosal permeability: albumin percentage, also called the “permeability index,” was elevated at 10 min postexposure only
(Krakowiak et al., 1998) | Human workers with bronchial asthma or healthy subjects (n = 10 each) | Formalin (assumed: test article NR): 0.5 mg/m^3^ for 2 hr with follow-up out to 24 hr | Nasal lavage cell and protein counts Note: changes were associated with scoring measures of nasal symptoms (e.g., sneezing; edema) | Increased eosinophils, leukocytes, total cell counts, and permeability index at 30 min after exposure, but not at 4 hr or 24 hr after exposure; N/C in basophils (changes were observed regardless of asthmatic designation) N/C in mast cell tryptase or eosinophil cationic protein | Low Confidence [formalin; short duration; small sample size; lack of investigator blinding (nonissue for automated albumin measures)]; NOTE: ACUTE; albumin percentage, aka “permeability index” was used to indicate mucosal permeability; no effect on FEV_1_, etc.
(Falk et al., 1994) | Human symptomatic for nasal distress (n = 7) or controls (n = 6) | Formalin (assumed from description of test article); Symptomatic: 0.021, 0.028, 0.073, 0.174 mg/m^3^; ≤2 hr; Healthy: 0.023, 0.29, 0.067, 0.127 mg/m^3^; ≤2 hr | Nasal mucosa swelling by rhinostereometry | FA increased mucosal swelling at ≥0.073 mg/m^3^ in symptomatic persons, but swelling was unchanged in healthy controls | Low Confidence [formalin; short duration; small sample size]; NOTE: ACUTE; assay is relevant to inflammation, but limited in scope and exposure contrast
(He et al., 2005) | Human student volunteers (n = 10) | Ocular exposure to wood-panel generated formaldehyde gas 0, 1, 2, or 3 mg/m^3^; 5 min/d for 4 d | Nasal lavage substance P | Substance P was increased significantly at 3 mg/m^3^ | Low Confidence [exposure route- unknown relevance of ocular exposure route to inhaled exposure level, but considered to be reasonable due to similarities in access of gas to trigeminal nerve endings for this endpoint; short duration and periodicity; somewhat small sample size]
(Bardet et al., 2014) | In vitro (human primary nasal cells); n=5 experiments (cells: one donor) | Formalin gas: 0.2 mg/m^3^ for 1 hr/d for 1, 2, or 3 d | Nasal cell cytokine secretion (at 72 hrs for all exposures) | Slight, statistically significant, decreased IL-8 with 3 exposures only; N/C in IL-6 | Not Informative [in vitro; formalin; short duration; small sample size; comparable in vivo inhaled exposure level unknown]
[underlined: Controlled-Exposure Studies in Animals, Animal Cells, or Immortalized Human Cells]
(Fujimaki et al., 2004b) | Female C3H mice (n = 5–6 per group) | PFA 0, 0.098, 0.49, or 2.46 mg/m^3^; 12 wks | Serum cytokines and neuropeptides (see explanation at right) | D/D increased Substance P without OVA (no change + OVA) at 2.46 mg/m^3^; FA decreased OVA-induced NGF elevation at 0.098–0.49 mg/m^3^ (N/C with FA alone) Body weight decreased at ≥0.49 mg/m^3^ | High or Medium Confidence [small sample size]; Note: although serum measure, discussed in the context of changes in the URT, so included here
(Fujimaki et al., 2004b) | Female C3H mice (n = 5–6 per group) | Sensitization: i.p. 10ug OVA prior to FA exposure; aerosol OVA boost for 6 min on wks 3, 6, 9, and 11 | | D/D increased Substance P without OVA (no change + OVA) at 2.46 mg/m^3^; FA decreased OVA-induced NGF elevation at 0.098–0.49 mg/m^3^ (N/C with FA alone) Body weight decreased at ≥0.49 mg/m^3^ | High or Medium Confidence [small sample size]; Note: although serum measure, discussed in the context of changes in the URT, so included here
(Monticello et al., 1989) | Young adult male rhesus monkeys (n = 3/group) | PFA 0 or 7.38 mg/m^3^ for 1 or 6 wk (6 hr/d, 5 d/wk) | Nasal histopathology | Goblet cell loss, hyperplasia, and neutrophil inflammatory response at 1 wk | High or Medium Confidence [high exposure level]; Note: n =3 monkeys/group considered a reasonable sample
(Andersen et al., 2010) | Male F344/CrlBR rats (n = 7–8) | PFA 0, 0.86, 2.46, 7.38, 12.3, or 18.5 mg/m^3^ for 1, 4, or 13 wk (6 hr/d, 5 d/wk) | Nasal histology Nasal mRNA analyses (Note: modeling results not considered) | mRNA changes: altered cellular immune response at 1 wk at 12.3–18.5 mg/m^3^, with changes in DNA repair and cell cycle at ≥ 2.46 mg/m^3^; by 4 wk, immune/injury response is lost; by 13 wk, pervasive changes noted | High or Medium Confidence; Note: unclear, indirect interpretability of mRNA profiling
Andersen et al., 2008) | Male F344 rats (n = 8 for histopath; n ≥5 for genomics) | PFA 0, 0.86, 2.46, or 7.38 mg/m^3^ for up to 3 wks (6 hr/d, 5 d/wk); also acute (18.5 mg/m^3^) and instillation | Nasal histopathology, and microarray (high flux regions) | Inflammatory cell infiltration was observed at 7.38 mg/m^3^ at ≥1-d exposure; microarray changes at ≥2.46 mg/m^3^ at 5 d, but only at 7.38 mg/m^3^ at 15 d (1 gene at 2.46 mg/m^3^, 1 d); mostly stress-response related | High or Medium Confidence; NOTE: unclear, indirect interpretability of genomic endpoints; note: nasal instillation caused more robust changes
(Woutersen et al., 1989) | Male Wistar rats (n>20/ group) | PFA 0, 0.12, 1.23, or 12.3 mg/m^3^ for 28 mos (6 hr/d, 5 d/wk) | Nasal pathology | No treatment-related changes at 0.12–1.23 mg/m^3^; evidence of damage, inflammation, proliferation at 12.3 mg/m^3^ | High or Medium Confidence
(Rager et al., 2014) | Male Fischer rats (n = 3 biological replicates/group) | PFA 0 or 2.46 mg/m^3^ for 7 d, 28 d or 28 d with 7 d recovery (6 hr/d) | miRNA microarray of nasal respiratory epithelium | Nasal miRNAs were changed after 7 d or 28 d (84 or 59 transcripts), not with recovery; associated with inflammation and immunity, or tumor suppression | High or Medium Confidence [very small sample size]; NOTE: unclear, indirect interpretability of endpoints
(Tsubone and Kawata, 1991) | Male Wistar rats (n = 6/ group; each rat received 2–4 exposures of PFA or control air) | PFA 0.39-5.78 mg/m^3^ through upper airway for 22 sec (under anesthesia) | Ethmoidal nerve activity (nasal trigeminal nerve branch) | Afferent nerve activity was increased by FA, with a 50% increase in activity at ≈2.2 mg/m^3^ (although FA stimulated nerve activity at all levels- ≈20% at 0.62 mg/m^3^) | High or Medium Confidence [short duration]; NOTE: ACUTE: surgical procedures considered internally controlled (since rats served as own controls)
(Kulle and Cooper, 1975) | Male SD rats (n = 5) | PFA 0.62, 1.23, 1.85, or 2.46 mg/m^3^ for 1 hr or 0.62–3.08 mg/m^3^ for 25 sec (with anesthesia) | Nasopalantine nerve responses (similar to ethmoidal in preliminary tests) | Sensory threshold from 25 sec exposure: 0.31 mg/m^3^ Trigeminal response to an odorant (amyl alcohol) is decreased at ≥0.62 mg/m^3^ FA | High or Medium Confidence [slightly small sample size; short duration]; NOTE: ACUTE; surgical procedures internally controlled
(Yonemitsu et al., 2013) | TRPA1 knockout (KO) or wild type (WT) mice (n = 3–5) | Formalin at up to 123 mg/m^3^ (varied by experiment and chamber location, but all exposures considered “excessive”); ACUTE | Responses related to effects on the trigeminal nerve | Formalin vapor (3 min) activated secondary trigeminal system neurons (according to c-fos activity) in WT but not KO mice.; Consistent with this, formalin vapor accelerated wakefulness and induced avoidance behaviors in WT but not KO mice; and labeling studies confirmed TRPA1 expression on trigeminal afferents innervating the nasal mucosa | High or Medium Confidence [small sample size; short duration; formalin; excessive levels; see below for explanation]; NOTE: ACUTE; effects of related chemicals such as acrolein were similarly blocked in KO mice. Given the difficult nature of studying this event, the consistency of effects across related chemicals, and the well-accepted role for TRPA1 in acrolein-induced sensory effects (based largely on(Bautista et al., 2006)), these results are judged to provide indirect evidence interpreted with high or medium confidence and not direct evidence interpreted with low confidence.
(Rager et al., 2013) | Male cynomolgus macques (n = 2–3/group) | PFA 0, 2.46, or 7.38 mg/m^3^ for 2 d (6 hr/d) | Nasal miRNA screen and molecular target verification | 3 and 13 miRNAs were dysregulated by exposure, including associations with decreased apoptosis signaling (at 2) and increased epithelial proliferation (at 6) | Low Confidence [short duration; n=2 primates: small sample size]; NOTE: Unclear direct relevance of miRNA changes
(Clement et al., 1987) | Female Wistar Rats (n=10) | PFA 0 or 18.5 mg/m^3^ for 12 wks (6 hr/d, 5 d/wk) | URT epithelial structure and junctional proteins by IHC and TEM | Basal lamina degeneration, and goblet cell hypertrophy of respiratory epithelium; FA reduced levels of junctional proteins but did not cause destroy the junctional complex when assessed by TEM; Note: body weight significantly decreased by FA (<5%) | Low Confidence [excessive exposure levels]
(Cassee et al., 1996b) | Male Wistar albino rats (≥3/group) | PFA 0, 1.23, 3.94, or 7.87 mg/m^3^ for 1 or 3 d (6 hr/d) | Nasal histopathology and biochemistry | Evidence of damage and inflammation at 3 d, ≥3.94 mg/m^3^ Increased GPx and NPSH (3 d, ≥3.94 mg/m^3^; latter at 1 d, 7.87 mg/m^3^ too), not GST, FDH, ADH, or GR in respiratory epithelium | Low Confidence [short duration; very small sample size]; NOTE: ACUTE or 3 d; NPSH: nonprotein sulfhydryl groups
(Cassee and Feron, 1994) | Male Wistar rats (n = 20/ group; n = 6+/endpoint) | PFA 4.43 mg/m^3^ for 3 d (intermittent) Note: weights decreased in all groups | Nasal enzyme activity Nasal GSH | Increased GPx N/C in ADH, GST, G6PDH, GR, or FDH N/C in cytosolic GSH (slightly increased); Note: rhinitis and necrosis also reported | Low Confidence [short duration and unclear periodicity; high exposure level]
(Abreu et al., 2016) | C57BL/6 mice (n = 12 M+F/treatment group and n = 6 M+F/control) | Formalin (assumed) 0, 0.25, 1.2, and 3.7 mg/m^3^ for 8 hr (aldehyde mixture data not included herein; authors noted some exposure crosscontamination) | Nasal epithelial histology (morphology only) (blinded measures 6–8 hr postexposure) | N/C in nasal epithelium, except small, but significant, decreases in cilia at 0.25 mg/m^3^ | Low Confidence [formalin; short duration and periodicity; some coexposure to acetaldehyde possible but unclear]; Note: ACUTE
(Monteiro-Riviere and Popp, 1986) | Male F344 rats (n = 3 examined in detail) | PFA 0, 0.62, 2.46, 7.38, or 18.5 mg/m^3^ for up to 4 d (6 hr/d); controls not air-exposed | URT respiratory epithelium ultra-structural pathology | Inflammation (neutrophil infiltration; goblet cell hypertrophy) at ≥7.38 mg/m^3^; duration-dependency shown | Low Confidence [short duration; very small sample size; controls not air exposed]; NOTE: no statistical comparisons of structural changes
(Mcnamara et al., 2007) | In vitro mouse and rat dorsal DRG neurons (n = 300+ neurons) or HEK293 cells (n ≥ 5); (note: relevance is as URT stimulus) | Formalin or methanol controls (levels irrelevant to inhalation exposure); ACUTE experiments | Activation and specific inhibition of “sensory nerve cell” activity | Formalin, but not methanol, specifically activated TRPA1 in vitro. This specific activation was confirmed using TRPA1 knockout DRG neurons as well as specific pharmacologic inhibitors. TRPA1 inhibition also reduced formalin-induced pain behaviors in vivo. | Low Confidence [in vitro; unknown exposure level relevance; short duration]; Note: ACUTE; methanol controls; categorized as low confidence rather than excluding due to less concern for methanol effects on receptors in nasal mucosa
(Tani et al., 1986) | Male rabbits (strain unspecified) n= unclear | Formalin 12.3 mg/m^3^ (acute) directly infused into either the URT (nasal) and/ or LRT (lung) | Pharmacologic intervention studies on respiratory and cardiac function (compared to acrolein and ammonia) | The effects of formaldehyde on respiration and heart rate were only observed with nasal exposure, not lung. Inhibition of afferent sensory nerve activity abrogated the formaldehyde effects. | Low Confidence [formalin; short duration; unknown sample size]; NOTE: ACUTE; categorized as low confidence rather than excluding due to less concern for methanol effects on receptors in nasal mucosa
(Kunkler et al., 2011) | In vitro trigeminal root ganglia (rat) neurons (n = 9–15) | Formalin (levels irrelevant to inhalation exposure); ACUTE experiments | Agonist/antagonist studies of TRP channel-mediated CGRP release | Formaldehyde stimulated release of CGRP from adult trigeminal neurons; (Note: inhibitor studies not tested on FA, but acrolein was through TRPA1) | Low Confidence [in vitro; formalin; short duration; high, unknown exposure level]; NOTE: ACUTE; categorized as low confidence rather than excluding due to less concern for methanol effects on receptors in nasal mucosa
(Zhao et al., 2020) | Male Balb/c mice (n = 3, pooled into single sample for nose and lung samples); 2 experiments by different researchers | Formalin 0, 3 mg/m^3^ for 2 wks (8 hr/d, 5 d/wk) | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies in nose, lung, spleen, and bone marrow | Nose (ex vivo) results: Decreased formation of BFU-E in both experiment I and II; Decreased formation of CFU-GM in experiment I; N/C in experiment II Nose (in vitro treatment): 400 uM formaldehyde significantly decreased BFU-E not CFU-GM formation (both nonsignificantly decreased across doses) | Low Confidence [formalin; small sample size; in vitro (for cell treatments)]
(Hester et al., 2003) | Male F344 rats; n = 3–4 | Formalin (assumed, based on description); nasal instillation (400 mM in 4 0 μL aliquot/nostril) | Respiratory epithelium gene expression | 24 of 1,185 genes upregulated, and 22 downregulated | Not Informative [formalin; short duration; very small sample size; high, unknown exposure level; exposure route]; NOTE: ACUTE
(Ohtsuka et al., 2003) | Male BN and F344 rats; n = 4/group | Formalin aerosol 1% for 3 hr/d for 5 d vs. water | Nasal mucosa cytokines and structure | Degeneration and neutrophil inflammation (F344> BN) Decreased IFN-γ and IL-2 in BN; N/C in F344; N/C in IL-4 or IL-5 in BN or F344 | Not Informative [formalin; short periodicity; small sample size; high, unknown exposure levels]
(Macpherson et al., 2007) | In vitro; n ≥ 7; transfected cells (HEK293T cells neuroendocrine; immortalized human kidney) | Formalin (levels irrelevant to inhalation exposure); ACUTE experiments | Activation and specific inhibition of “sensory nerve cell” activity | Formalin activated TRPA1. This selective activation was confirmed by inhibition of pain-related behaviors induced by formalin in vivo. | Not Informative [in vitro; formalin; short duration; high, unknown exposure level; limited reporting]; NOTE: ACUTE

#### Evaluation of Mechanistic Evidence Related to Changes in Lower Respiratory Tract (LRT)

##### Markers of Structural Changes, Immune response, Inflammation or Oxidative Stress

Table B-43 LRT (e.g., lung, trachea, BAL) markers of structural modification, immune response, inflammation, or oxidative stress

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
Observational Epidemiology Studies
(Franklin et al., 2000) | Human healthy children (n = 224; age ≈9.5 year); | FA levels in bedroom and living room were dichotomized into > or < 0.062 mg/m^3^; duration unknown | exhaled nitric oxide (eNO); Note: technique used excludes NO originating from the upper airway | eNO (“reflects airway inflammation”) significantly increased in children of homes with higher FA levels, after correcting for multiple other variables | High or Medium Confidence [limited exposure contrast; accuracy of single measure questionable]; Note: authors suggest species differences in inflammation locale
(Bentayeb et al., 2015) | Human elderly (>65 years) European nursing home individuals (n = 600 from 20 homes) | Indoor FA levels in main common room ranged from approximately 0.005–0.01 mg/m^3^ (median ≈0.006) over 1 wk of sampling; duration unknown | eNO (marker of lower airway inflammation) eCO (marker of CO exhalation and smoking) | FA was not associated with eNO FA was associated with increased eCO Note: FA was associated with increased reported COPD and FVC, but not FEV1, asthma diagnosis or symptoms, or cough | High or Medium Confidence [limited exposure contrast; unclear whether adjusted for coexposures]; Note: PM co-exposure was not associated with eNO or eCO; NO_2_ was associated with decreased eNO
(Flamant-Hulin et al., 2010) | Human school children (34 asthmatics; 70 nonasthmatics); | [Low] yards: 0.0036 (0.0024–0.0044) mg/m^3^ and rooms: 0.025 (0.013–0.036) mg/m^3^ [High] yards: 0.0058 (0.0049–0.0068) mg/m^3^ and rooms: 0.044 (0.038–0.047) mg/m^3^; unknown duration | Fractional exhaled nitric oxide (FeNO)—“reliable, noninvasive marker of airway inflammation” [Note: “nasal contamination” was prevented] | FeNO significantly increased in both nonasthmatics and asthmatics with high versus low FA exposure in classrooms, but not schoolyards; in nonasthmatics, a stronger association was found for atopic versus nonatopic children | High or Medium Confidence [accuracy of single measure questionable]; Note: authors hypothesized that atopic status might modify airway response to formaldehyde; called changes “bronchial inflammation”
(Roda et al., 2011) | French infants (n = 2,940 with assessment at birth and 12 mos) | Median 0.020 mg/m^3^; IQR 0.014–0.027 mg/m^3^; LOD 0.008 mg/m^3^. | LRT infections (with or without wheeze) Note: although URT infections were queried, these data were NR | Significantly increased LRT infection: 32% or 41% increase per 0.0124 mg/m^3^ increase in formaldehyde (without and with wheeze, respectively) | High or Medium Confidence [specificity and sensitivity of predictive model not tested on a separate sample]
(Rumchev et al., 2002) | Australian children (ages 6-36 mos); 88 cases, 104 controls | Mean 0.030 and 0.028 and maximum 0.224 and 0.190 mg/m^3^, respectively, in bedroom and living room. | Lower respiratory tract infection involving wheezing (assuming misclassification of a many of the discharges as asthma rather than infection) | Increased emergency room visits for this case definition | Low Confidence [recruitment process not described; uncertainty as to how well this case definition describes LRT infection and the length of time between emergency room visit and subsequent exposure measure]
Controlled-Exposure Studies in Humans or Primary Human Cells
(Casset et al., 2006) | Human (n = 19 with mild asthma and allergy to mite allergen) | Formalin 0.1 mg/m^3^ for 30 min; placebo at ≈0.03 mg/m^3^ double-blind randomized; restricted to mouth breathing only | Sputum (lower airway mucus) eosinophils and ECP | Authors note a trend, not statistically significant, towards increased eosinophil counts (≈38 ± 9% vs. 11 ± 3%, FA vs. air controls), and an increase in ECP (439 ± 171 vs. 156 ± 58 μg/l, FA vs. air controls) | Low Confidence [formalin; short duration; not clear that restriction to mouth breathing is realistic for typical inhalation]; NOTE: ACUTE; within-subjects comparison between air and FA
(Ezratty et al., 2007) | Human (n = 12 intermittent asthmatics with allergy to pollen) | Formalin 0.5 mg/m^3^ for 60 min; randomized allocation (no nonexposed controls) | Sputum (lower airway mucus) cell counts and released factors | N/C in sputum Total cell counts, WBC subtypes, or factors (e.g., ILs, MCP, TNF) | Low Confidence [formalin; short duration]; NOTE: all exposed to both air and FA: internally controlled
Controlled-Exposure Studies in Animals, Animal Cells, or Immortalized Human Cells
(Fujimaki et al., 2004b) | Female C3H mice (n = 5–6 per group) | PFA 0, 0.098, 0.49, 2.46 mg/m^3^; 12 wks | BAL cell counts BAL cytokines and neuropeptides | No significant changes in cell counts with FA alone; macrophages and eosinophils increased at 2.46 mg/m^3^ with OVA+FA; N/C in neutrophils or lymphocytes; No significant changes in cytokines with FA alone (NGF was D/D increased) FA with OVA D/D decreased IL-1β at 2.46 mg/m^3^ and NGF at 0.098–0.49 mg/m^3^; N/C in TNF-α, GM-CSF, or IL-6; MCP-1, MIP-1a, and eotaxin were not detectable Body weight decreased at ≥0.49 mg/m^3^ | High or Medium Confidence [small sample size for some groups/endpoints]; Note: MIP-1α, eotaxin, MCP-1, BDNF, and Substance P levels insufficient for testing
(Fujimaki et al., 2004b) | Female C3H mice (n = 5–6 per group) | Sensitization: i.p. 10 µg OVA prior to FA exposure; aerosol OVA boost for 6 min on wks 3, 6, 9, and 11 | | | High or Medium Confidence [small sample size for some groups/endpoints]; Note: MIP-1α, eotaxin, MCP-1, BDNF, and Substance P levels insufficient for testing
(Riedel et al., 1996) | Female Dunkin-Hartley guinea pigs (n = 3) | Formaldehyde (bottled pressurized gas) 0, 0.13, 0.31 mg/m^3^ for 5 d (8 hr/d) | Airway histology and morphometry | With FA, lung bronchi had intramural edema (wall thickening) by morphometry; no evidence of cellular lower airway inflammation by histology | High or Medium Confidence [small sample size]; Note: histology after FA with OVA not examined
(Riedel et al., 1996) | Female Dunkin-Hartley guinea pigs (n = 3) | Sensitization: 0.5% inhaled OVA; OVA boost at 2 wk Challenge: 1% inhaled OVA 1 wk later | | With FA, lung bronchi had intramural edema (wall thickening) by morphometry; no evidence of cellular lower airway inflammation by histology | High or Medium Confidence [small sample size]; Note: histology after FA with OVA not examined
(Ito et al., 1996) | Male Wistar rats (n = 7) | Formalin (with MeOH controls) 2.46, 6.15, 18.5, or 55.4 mg/m^3^ for 10 min | Airway microvascular leakage (Evans blue) in trachea and main bronchi | D/D increased leakage at ≥6.15 mg/m^3^, which resolved in <20 min Leakage at 18.5 mg/m^3^ was inhibited by NK1 receptor antagonism, but not by hista-mine H1 or bradykinin B2 R antagonists 55.4 mg/m^3^ MeOH alone induced slight leakage in main bronchi, but not trachea) | High or Medium Confidence [short duration]; Note: figure comparisons presented against room air, not MeOH, controls, but comparisons made to MeOH controls in text
(Jakab, 1992) | In vivo and Ex vivo Female Swiss mice (n = 5+ mice/determination) | PFA 0,0.62 1.23, 6.15, 12.3, or 18.5 mg/m^3^ for 4–18 hr or 4 d (4 hr/d); ± carbon black | Pulmonary bactericidal activity to inhaled Staphylococcus And ex vivo alveolar macrophage function | Pulmonary antibacterial activity was reduced: at 1.23 mg/m^3^ for 18 hr before and 4 hr postbacterial challenge (postexposure alone reduced at 18.5 mg/m^3^); N/C in ex vivo alveolar macrophage Fc receptor-mediated phagocytosis of RBCs at 6.15 mg/m^3^ for 4 d (FA + carbon black, but not FA alone, caused a robust decrease) | High or Medium Confidence [short duration]—in vivo pulmonary bactericidal activity; Note: ACUTE; Low Confidence [ex vivo; short duration]
(Swiecichowski et al., 1993) | Male Hartley guinea pigs (n = 5–12/group) | PFA at 4.18 mg/m^3^ for 2 or 8 hrs (multiple experiments) | Airway Histology (trachea) | No change histological evidence of cell infiltration or epithelial damage up to 96 hr after exposure to 4.18 mg/m^3^ for 8 hr | High or Medium Confidence at 1.23 mg/m^3^ and above [short duration]; Low Confidence below 1.23 mg/m^3^ and ex vivo [ex vivo; sample size of 5 at 1 or more levels below 1 ppm]; NOTE: ACUTE
(Ozen et al., 2003a) | Male albino Wistar rats (n = 6) | PFA at 6.15 and 12.3 mg/m^3^ for 4 or 13 wks (8 hr/d) | Lung tissue homogenate measures of trace elements | Zn was dose-dependently decreased (≥6.15 mg/m^3^ for both exposure durations; Fe was dose-dependently increased (≥6.15 mg/m^3^ with 13 wk; significant only at 12.3 mg/m^3^ after 4 wk); Cu was unchanged | High or Medium Confidence [high levels]; NOTE: unclear relevance of endpoints; authors claim Fe change linked to oxidative stress and Zn change linked to decreased DNA synthesis, but no direct evidence
(Aydin et al., 2014) | Male SD rats (n=6/group) | Test article unclear, but appears to be formalin in this experiment at 0, 6.48 (low), 12.3 (moderate), or 18.7 mg/m^3^ for 4 wk (8 hr/d, 5 d/wk) | Lung tissue total antioxidant and total oxidant levels (TAS and TOS; kit uses vitamin E and H_2_O_2_ as reference, respectively; Lung tissue oxidative stress index (OSI: TOS/TAS) and apoptotic index Lung irisin (hormone may regulate obesity) | Increased TOS and OSI, and decreased TAS and irisin, at ≥ 12.3 mg/m^3^ formaldehyde; Increased lung apoptotic index at ≥6.48 mg/m^3^; Note: Carnosine supplementation reduced changes. | Low Confidence [formalin; high levels]
(Luo et al., 2013) | In vitro and ex vivo (intact trachea) from SD rats (sex NR); n= as low as 4 (some inhibitor assays), as high as 28 (trachea) | Formalin (assumed, test article NR; levels irrelevant to inhalation exposure); ACUTE (bath application) experiments | Isc currents in trachea and epithelium from trachea with various inhibitors; TRPV channel expression and labeling | Formaldehyde caused a dose-dependent, sustained increase in currents in isolated trachea and airway epithelia TRPV-1 channels were localized to intraepithelial nerve endings and inhibition of TRPV-1 or substance P activity (blocking NK-1R) inhibited current increases; Cl- released in response to formaldehyde was blocked several Cl channel blockers and involed cAMP | Low Confidence [in vitro and ex vivo (intact trachea); formalin; unknown exposure level relevance]; Note: ACUTE, some inhibition experiments had n = 4, but magnitude of inhibition was robust with small variabilty
(Lundberg and Saria, 1983) | Male SD rats (sample size NR) | Direct injection of formaldehyde (assumed to be formalin); 50 μL volume unknown comparison to inhalation exposure | Tracheal mucosal reactivity (Evans blue extravasation) | Formaldehyde injection caused extravasation which was reduced or abolished by capsaicin pretreatment | Low Confidence [formalin; inferred high levels; short duration; nonspecific reporting]; NOTE: ACUTE
(Larsen et al., 2013) | Male BALB/cA mice (n = 10/group) | PFA 0.49, 2.21, or 4.9–7.0 (dry vs. humid air) mg/m^3^; 60 min | BAL counts | FA did not affect BAL “degree of lung inflammation” (data not shown; unclear if this reflects comparisons of total cell counts or comparisons of individual cell types, as data were presented for OVA, i.e., neutrophils, lymphocytes, eosinophils, macrophages) | Low Confidence [short duration; for BAL endpoints: poor reporting: FA alone groups data NR; OVA without FA and OVA with FA groups combined]; NOTE: ACUTE
(Larsen et al., 2013) | Male BALB/cA mice (n = 10/group) | Sensitization: pre-FA i.p. 1 µg OVA, with 0.1 µg OVA boosts i.p. on days 14 and 21 (note: FA on Day 31) Challenge: 0.2% OVA aerosol for 20 min on Days 29 and 30 | | | Low Confidence [short duration; for BAL endpoints: poor reporting: FA alone groups data NR; OVA without FA and OVA with FA groups combined]; NOTE: ACUTE
(Wu et al., 2013) | Male Balb/c mice (n = 8/group) | Formalin 0 or 3 mg/m^3^ for 4 wk (6 hr/d, 5 d/wk) with or without OVA aerosol | BALF cell counts Lung tissue cytokines, neuropeptides, and histology/IHC | Total cells, eosinophils, and lymphocytes were increased in BALF by FA alone, and all of these cells (minus lymphocytes but plus neutrophils) were increased more robustly by FA+ OVA; Histopathology: increased inflammation FA increased lung IL-4, IL-1β, substance P, and CGRP, but not IFNγ; more robustly by FA+OVA (peptide changes by IHC also) TRPA1 and TRPV1 antagonists reduced FA+OVA-induced eosinophil counts (anti-TRPA1 also decreased neutrophils), and lung factors (except IL-1) | Low Confidence [formalin; pharmacological interventions did not include effects of FA alone]
(Wu et al., 2013) | Male Balb/c mice (n = 8/group) | Sensitization: s.c. 80 μg OVA on Days 10, 18, and 25 Challenge: 1% OVA aerosol 30 min/d on Days 29–35 | | | Low Confidence [formalin; pharmacological interventions did not include effects of FA alone]
(Qiao et al., 2009) | Male Wistar rats (n = 8/group) | Formalin 0, 0.51 or 3.08 mg/m^3^ for 3 wk (6 hr/d) | BALF cell counts Lung histology and cytokine levels | “slight but insignificant pulmonary abnormalities” with FA alone; OVA 3.18 mg/m^3^ changed airway structure N/C in BAL total cells or eosinophils with 3.18 mg/m^3^, but ≥0.51 mg/m^3^ dose-dependently increased both in presence of OVA; 3.18 mg/m^3^ FA alone increased IFNγ and decreased IL-4; FA+OVA increased IL-4 | Low Confidence [formalin]
(Qiao et al., 2009) | Male Wistar rats (n = 8/group) | Sensitization: i.p. OVA on Days 10 and 18 Challenge: 1% OVA 30 min/d for 7 d | | | Low Confidence [formalin]
(Liu et al., 2011) | Male Balb/c mice (n = 6/ group) | Formalin 0, 0.5, or 3 mg/m^3^ for 21 d (6 hr/d) | BALF cell counts Pulmonary histology and cytokines | Cell infiltration and airway remodeling in 3 mg/m^3^ FA + OVA; Increased % Eosinophils at ≥ 0.5 mg/m^3^, which is amplified by OVA; N/C IFNγ Increased lung IL-4 and IL-6 at 3 mg/m^3^; with OVA, this is observed at 0.5 mg/m^3^ | Low Confidence [formalin]
(Liu et al., 2011) | Male Balb/c mice (n = 6/ group) | Sensitization: i.v. 20 mg OVA on Day 10 and 1 Challenge: 1% OVA aerosol for 30 min/d for 7 d | | | Low Confidence [formalin]
(Ye et al., 2013) | Male Balb/c mice (n ≥9/ group/ endpoint) | Formalin 0, 0.5, 1, or 3 mg/m^3^ for 7 d (8 hr/d) | ROS (dichlorohydro-flourescein and MDA) and GSH in Lung | Dose-dependent decrease in GSH levels in lung at ≥0.5 mg/m^3^; Dose-dependent increase in DCFH and MDA in lung at ≥1 mg/m^3^; Co-administered GSH attenuated effects | Low Confidence [formalin]
(Abreu et al., 2016) | C57BL/6 mice (n = 12 M+F/treatment group and n = 6 M+F/control) | Formalin (assumed) 0, 0.25, 1.2, and 3.7 mg/m^3^ for 8 hr (aldehyde mixture data not included herein; authors noted some exposure crosscontamination) | Lung histology (cells and morphology) (blinded measures 6–8 hr postexposure) Lung cytokine, catalase, and SOD levels/activity | FA increased distended alveoli at 3.7 mg/m^3^; N/C in total mononuclear or polymorphonuclear cells; N/C in IL-1, IL-6, TNF, CCL2, or MIP-2, or in antioxidants; increased keratinocyte chemoattractant at 0.25 mg/m^3^ only Note: N/C in lung mechanics except increased airway inertance (might indicate an impedence of airflow) at 3.7 mg/m^3^ | Low Confidence [formalin; short duration and periodicity; some coexposure to acetaldehyde possible- unclear]; Note: ACUTE
(Sandikci et al., 2007b) | SD rats (n = 6/group) at GD1 [I], PND1 [II], PND28 [III] or adults [IV] | Formalin (assumed: test article NR): 0 or 7.38 mg/m^3^ for 6 wks (8 hr/d, 7 d/wk) | BALT T lymphocyte CD4+, CD8+ counts (by IHC) | Increased BALT T lymphocytes (ANAE+ as marker); CD4+ T cell counts and size of BALT increased in Groups III and IV; CD8+ T cell counts increased in Group III Note: body weight was significantly decreased in Groups I and II | Low Confidence [formalin; high exposure levels]; Note: limited assays
(Sandikci et al., 2007a) | Female SD rats at GD1 [i], PND1 [ii], PND 28 [iii], or PND90 [iv] (n = 6) | Formalin (assumed; test article NR) 0, 7.38 mg/m^3^ for 6 wks (8 hr/d, 7 d/wk) | BALT T lymphocyte counts; BALT size Note: body weight decreased by FA in groups i and ii | CD4+ cell counts increased in groups iii and iv; CD8+ cell counts increased in group iii (group iv N/S increased) Increased size of BALT in adults (iii & iv) | Low Confidence [formalin; high exposure levels]
(Sandikci et al., 2009) | SD rats (n = 9/group) at GD1 [I], PND28 [II] or adults [III] | Formalin (assumed: test article NR): 0 or 7.38 mg/m^3^ for 6 wks (8 hr/d, 7 d/wk) | Apoptotic cell counts in lung and BALT | Apoptotic cells increased in lung and BALT in Groups II and III, but not Group; I(authors speculated apoptotic BALT cells were lymphocytes) | Low Confidence [formalin; high exposure levels]
(Jung et al., 2007) | Female C57BL/6 mice (n = 10/ group) | Formalin (assumed; test article NR) 0, 6.15, 12.3 mg/m^3^ for 2 wk (6 hr/d, 5 d/wk) | Lung oxidative stress (intracellular, by flow) BAL and lung homogenate counts, and histopath. Cytokine mRNA and protein | Oxidative stress (DCFH-DA) at ≥6.15 mg/m^3^; Total BAL cells increased (2-fold) at 12.3 mg/m^3^; Slight changes in B220+ B cells (↓) and CD3+ or CD4+ T cells (↑) were not interpreted as significant; CD8+ T cells were ↑, only slightly; N/C in neutrophils Large increase in eosinophil counts from BAL, and in flow counts and gene expression of lung tissue at 12.3 mg/m^3^, eosinophil infiltration, and epithelial damage, by histopath at ≥6.15 mg/m^3^ Increased IL-4, IL-5, and IL-1β (not IL-13); in lung at 6.15 and 12.3 mg/m^3^ body weights decreased ≈10% | Low Confidence [formalin; high exposure levels; statistical significance of flow data NR]; Note: Th2 cytokines
(Sul et al., 2007) | Male SD rats (n = 10/group) | Formalin (assumed; test article NR) 0, 6.15, 12.3 mg/m^3^ for 2 wks | Lung tissue oxidative stress and mRNA array | Lipid peroxidation (MDA) and protein oxidation were increased at 12.3 mg/m^3^ Changes in 21 genes, including D/D decrease in 3 immune-related genes: HSP70_1a_, complement 4 binding protein, and Fc receptor IgG low affinity III | Low Confidence [formalin; high levels]; NOTE: utility of mRNA results by themselves unclear
(Lu et al., 2005) | Male Kun Ming mice (n = 5) | Formalin 0, 0.5, 1, or 3 mg/m^3^ for 10 d (6 hr/d) | BALF IL-4 (undetected in serum) | D/D Increased IL-4 at ≥1 mg/m^3^ FA Blocked by vanilloid (TRPV) receptor antagonist, CPZ | Low Confidence [formalin; small sample size]
(Ahn et al., 2010) | Male SD rats (n = 4/group) | Formalin (assumed; test article NR) 0, 2.46, or 24.6 mg/m^3^ for 2 wk (6 hr/d) | BAL fluid proteomic analysis | 6 proteins increased (3 inflammatory serpins, anti-inflammatory annexin, an erythrocyte protein associated with trauma or inflammation, and a metabolic enzyme); 5 proteins were decreased | Low Confidence [formalin]; NOTE: unclear utility of measures
(Kimura et al., 2010) | Male Wistar (n = 5–6) | Formalin 1.23, 6.15, 18.5, or 55.4 mg/m^3^ for up to 45 min | Airway microvascular leakage (lung- main bronchi and trachea) BALF counts of leukocytes; Shed epithelial cells in BALF | D/D increase leakage by 15 min at ≥ 1.23 mg/m^3^; not exacerbated with longer/repeated exposure; Note: Leakage induced by substance P was not inhibited by pre-FA exposure, but preinhalation of the same mg/m^3^ abolished FA-induced leakage and pre-FA inhibited capsaicin-induced leakage; however, 20 hr between exposures allows for recovery of tachykinins and leakage by FA exposure; Inhibition of mast cell activation (H1 receptor antagonist), but not cyclooxygenase products (indomethacin), blocked FA leakage at 6.15 mg/m^3^; increased shed epithelial cells 20 hr, but not immediately, after 6.15 mg/m^3^ for 30 min; Increased BALF neutrophils with preinhalation at 6.15 mg/m^3^, but N/C eosinophils or mononuclear cells | Low Confidence [formalin; small sample size; short duration]; Note: Authors hypothesize preinhalation of FA depletes the amount of tachykinins available at the target site (but not desensitization of NK1 receptors), in part b/c capsaicin can no longer induce a response; also, because of recovery, up to 6.15 mg/m^3^ does not cause irreversible damage to airway sensory nerves, but that prolonged exposure (≥7 d) might exacerbate neurogenic airway inflammation
(Dallas et al., 1987 | Male SD rats (n = 2/ timepoint; unclear reporting) | PFA 0, 0.62, 3.69, or 18.5 mg/m^3^ for 1 wk to 24 wk (6 hr/d, 5 d/wk) | Flow cytometry DNA/RNA analysis of alveolar cell proliferation/ health | Increased RNA index in alveolar cells at all FA levels at 1 wk; only at ≥ 3.69 mg/m^3^ at 8 wk; N/C in DNA (e.g., % S phase); [Note: same alveolar samples had chromatid breaks at 18.5 mg/m^3^] | Low Confidence [small sample size; unclear reporting]; NOTE: unclear specificity/ utility of methods
(Kim et al., 2013a) | Female C57BL/6 mice (n = 5 “experiments”; number of mice/ group unclear) | Formalin (assumed; test article NR) 0, 6.15, or 12.3 mg/m^3^ for 2–3 wk (6 hr/d, 5 d/wk) | Lung cell counts BAL cell counts Ex vivo cellular functional assays | N/C in lung tissue total cells, but number of NK1 cells markedly decreased (this recovered by 2 wks postexposure) at 12.3 mg/m^3^; Lung NK1 cell mRNA and protein markers (IFNγ, perforin, and CD122) were D/D decreased at ≥ 6.15 mg/m^3^; BAL total cells increased, but number of NK cells decreased at 12.3 mg/m^3^ N/C in other lung or BAL lymphocyte populations (e.g., % CD4+ or CD8+ cells) | Low Confidence [formalin; high levels; small sample size]; Not Informative: ex vivo experiments or in vitro FA treatment of NK precursors showing reduced differentiation to mature cells
(Sadakane et al., 2002) | Male ICR mice (n = 9 or 18) | Formalin 0.5% for 4 wk (15 min/wk) | Lung IHC cell counts and cytokine analysis | N/C in lung eosinophil recruitment or goblet cell proliferation by FA alone, but Der f-induced eosinophil recruitment was exacerbated by FA; Increased RANTES in lung by FA alone, and exacerbated increase to Der fchanges with FA for IL-5 and RANTES; N/C in lung IL-2 or IL-4 | Low Confidence [formalin; unquantified high levels; short periodicity]
(Sadakane et al., 2002) | Male ICR mice (n = 9 or 18) | Sensitization: i.p. with 3 mg/mL Der f (house dust mite allergen) prior to FA; Challenge: intratracheal 10 μg Der f 3 hr after last exposure (note: measures 3 d later) | | | Low Confidence [formalin; unquantified high levels; short periodicity]
(Sandikci et al., 2007a) | Female SD rats at PND1, PND28, or PND90 (n = 3) | Formalin (assumed; test article NR) 0 or 7.38 mg/m^3^ for 6 wk (8 hr/d, 7 d/wk) | Lung and BALT histology | N/C in exposed PND1 group Increased apoptotic cells in lungs and; BALT of PND28 and PND90 groups; Authors: apop. cells likely lymphocytes | Low Confidence [formalin; high level; small sample size]
(Matsuoka et al., 2010) | Male ICR mice (n ≥ 7) | Formalin at 0.12 mg/m^3^ for up to 24 hr; also, a single experiment at 3.69 mg/m^3^ for 24 hr | lung ROS (8OHdG) and NO metabolites (nitrates/ nitrites); at 3.69 mg/m^3^: LPS response | Decreased ROS lung; N/C in NOs or lung NOs after LPS injection | Low Confidence [formalin; short duration]; NOTE: ACUTE
(Yan et al., 2005) | Male Kun Ming mice (n = 6) | Mixture (test article wood panels) 0, 0.5, 1, or 3 mg/m^3^ for 72 hr (24 hr/d) | Lung NOS activity and NO measurement | Increased NOS activity at 3 mg/m^3^ FA (p = 0.06 at 1 mg/m^3^); NO was detected more frequently in samples from 3 mg/m^3^ FA group (50% vs. 17%) | Low Confidence [wood panel exposure; lack of controls for coexposure; short duration]; NOTE: NO detection did not include statistical comparisons
(Dinsdale et al., 1993) | Male SD rats (n = 4, 6, or 10) | PFA or Formalin 12.3 mg/m^3^ for 4 d (6 hr/d) | Lung enzymes (in BAL or tissue) Lung histology | Increased cytochrome P450 and decreased γ-glutamyl transpeptidase with PFA exposure (not with formalin) No abnormalities (i.e., signs of injury or repair) by histology | Low Confidence [small sample size; excessively high levels; short duration]; NOTE: Endpoints not No abnormalities (i.e., signs of injury or very informative for inflammation (injury response, possibly)
(Rager et al., 2011) | In vitro (human lung cancer cell line); n = 6 replicates | PFA 1.23 mg/m^3^ for 4 hr or air controls | In vitro epithelial cell miRNA microarray and IL-8 secretion | Increased IL-8 release >16-fold with FA 89 miRNAs were downregulated by FA; the 4 most robust were associated with inflammatory response pathways | Low Confidence [in vitro; short duration; exposure level comparability to inhalation unclear]
(Zhao et al., 2020) | Male Balb/c mice (n = 3, pooled into single sample for nose and lung samples); 2 experiments by different researchers | Formalin 0, 3 mg/m^3^ for 2 wks (8 hr/d, 5 d/wk) | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies in nose, lung, spleen, and bone marrow | Lung (ex vivo) results: Decreased formation of BFU-E in experiment II; N/C in experiment I Decreased formation of CFU-GM in experiment II; N/C in experiment I Lung (in vitro treatment): Up to 400 uM formaldehyde caused N/C in BFU-E not CFU-GM formation | Low Confidence [formalin; small sample size; in vitro (for cell treatments)]
(Maiellaro et al., 2014) | Pregnant Wistar rats (n = 5; note: individual pup data for n = 10 pups did not appear to account for litters) | Formalin 0.92 mg/m^3^ from GD1-GD21: 1 hr/d, 5 d/wk | BAL cell counts and factors Lung factors | N/C in parental BAL total cells, monocytes, lymphocytes, or granulocytes N/C in parental lung IL-4, IL-6 or IL-10; Decreased birth weight in offspring 24 hr after OVA challenge, offspring have: decreased BAL total cells, mononuclear cells, neutrophils, and eosinophils; Increased BAL IL-10, but decreased IL-6 and TNFα (N/C in IL-4) | Not Informative [formalin, short periodicity; small sample size; offspring comparisons do not include FA alone; did not appear to account for litter effects]
(Maiellaro et al., 2014) | Pregnant Wistar rats (n = 5; note: individual pup data for n = 10 pups did not appear to account for litters) | Sensitization: s.c. 10 μg OVA with sc boost after 7 d Challenge: 7 d later, 1% OVA aerosol 15 min/d, 3 d | | | Not Informative [formalin, short periodicity; small sample size; offspring comparisons do not include FA alone; did not appear to account for litter effects]
(Maiellaro et al., 2016) | Pregnant Wistar rats (n = 5 dams; note: individual pup data for n = 10 pups did not appear to account for litters) | Formalin 6.13 mg/m^3^ from GD1-GD21: 1 hr/d, 5 d/wk | BAL cell counts and factors in pups on ≈PND45 | Increased (amplified) total BAL leukocytes Increased (amplified) BAL mononuclear cells and neutrophils; Increased (amplified) myeloperoxidase Decreased (slightly reduced) eosinophils and eosinophil peroxidase | Not Informative [formalin, short periodicity; small sample size; offspring comparisons do not include FA alone; did not appear to account for litter effects]
(Maiellaro et al., 2016) | Pregnant Wistar rats (n = 5 dams; note: individual pup data for n = 10 pups did not appear to account for litters) | Sensitization on PND 30: s.c. 10 μg OVA Challenge: 14d later, 1% OVA aerosol 15 min/d, 3 d | | | Not Informative [formalin, short periodicity; small sample size; offspring comparisons do not include FA alone; did not appear to account for litter effects]
(Silva Ibrahim et al., 2015) | Pregnant Wistar rats (n = 5 dams; 10 pups/group for experiments; note: individual pup data for n = 10 pups did not appear to account for litters) | Formalin 0.92 mg/m^3^ from GDs 1–21: 1 hr/d, 5 d/wk | Cell number, cytokine and neutrophil marker (MPO) in BAL Function of BAL cells Lung gene and proteins | 24 hr after LPS challenge, offspring exposed to formaldehyde have reduced immune responses to LPS (i.e., decreased BAL cells and granulocytes- N/C in lymphocytes or monocytes; decreased MPO and oxidative burst- N/C in phagocytosis; decreased IL-6 and increased IFN and IL-10; decreased TLR4 and NFkB) | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects]
(Silva Ibrahim et al., 2015) | Pregnant Wistar rats (n = 5 dams; 10 pups/group for experiments; note: individual pup data for n = 10 pups did not appear to account for litters) | Randomly assigned pups all received 5 mg/kg lipopolysacharride (LPS) injections at PND 30 | | | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects]
(Ibrahim et al., 2016) | Pregnant Wistar rats (n = 5 dams; 10 pups/ group for experiments; note: individual pup data for n = 10 pups did not appear to account for litters) | Formalin 0.92 mg/m^3^ from GDs 1–21: 1 hr/d, 5 d/wk | Total BAL cell number and cytokine gene expression | Increased cell number by LPS was reduced in offspring exposed to formaldehyde Formaldehyde increased IFN expression, decreased IL-6, TLR4, and NF-kB expression, and caused N/C in IL-10, as compared to LPS | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects]; Note: effects rescued by vitamin C
(Ibrahim et al., 2016) | Pregnant Wistar rats (n = 5 dams; 10 pups/ group for experiments; note: individual pup data for n = 10 pups did not appear to account for litters) | Randomly assigned pups all received 5 mg/kg lipopolysacharride (LPS) injections at PND 30 | | | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects]; Note: effects rescued by vitamin C
(da Silva et al., 2015) | Male Wistar rats (n = 6/ group) | Formalin 1% for 3 d (90 min/d); rats exposed in static chambers 5 rats/time | BAL cell counts Lung vascular permeability; BAL and lung cytokines (all measures at 24 hr postexposure except permeability, which was immediate) | FA increased total BAL cells, activated mast cells, and neutrophils (latter based on myeloperoxidase activity); FA did not change trachea permeability (Evans blue), but did increase it in lung parenchyma and bronchii; FA increased TNF, IL_6, and N/C IL-10 in BAL, and increased IL-10, but not IL-6 mRNA in lung tissue; Note: while reduced effects were reported as reduced with laser therapy, laser therapy-only controls were not used | Not Informative [formalin; unquantified high levels; static exposure chamber and group exposure; short duration and periodicity]
(Murta et al., 2016) | Male Fischer rats (n = 7) | Formalin (assumed) 1%, 5%, or 10% for 5 d (3 × 20 min/d) | BAL cell counts Lung histopathology and chemokine levels | FA increased total leukocyte, macrophages at 10%, and lymphocytes at ≥5%; N/C in neutrophils or eosinophils; ≥5% caused lung parenchyma damage; ≥1% increased CCL5 and 10% CCL2 (N/C in CCL3) | Not Informative [formalin; unquantified high levels; static exposure chamber; short periodicity]
(Kilburn and Mckenzie, 1978) | Male and female Syrian golden hamster (n = 6–14) | PFA “low”: 3.69 or 7.38 mg/m^3^ or “high”: ≥246 mg/m^3^ for 4 hr; alone, with carbon dust, or evaporated onto carbon | Lower airway PMN Leukocyte recruitment and cellular changes by histology | Although cytotoxic effects were observed at ≥3.69 mg/m^3^, FA alone did not induce PMN leukocyte recruitment; FA + carbon caused leukocyte recruitment 2 hr postexposure, which peaked at ≈20 hr and resolved by 1 wk; recruitment was similar at “low” and “high” levels | Not Informative [short duration, precision of exposure levels unclear; reporting difficult to follow, and data NR for all exposure levels indicated as tested; nonexposed controls did not appear to be included]
(Persoz et al., 2010) | In vitro (human immortalized lung cells); n = 4 experiments | Formalin gas: 0.050 mg/m^3^ for 30 min, ± TNFα sensitization | Lung cell Cytokine secretion (at 24 hr post-FA) | N/C in IL-6, IL-8, or MCP-1 without TNF α sensitization; Increased IL-8 only with sensitization; Note: air exposure alone increased IL-8 | Not Informative [formalin; in vitro; short duration; unknown exposure level relevance; small sample size; controls exhibited effects from air-only exposure]
(Persoz et al., 2011) | In vitro (human immortalized lung cells); n = 4 experiments | Formalin gas: 0.050 mg/m^3^ for 30 min, with or without aspergillus spores (Asp) | Lung cell cytokine secretion (at 24 hr post-FA) | N/C in IL-8 or MCP-1 mRNA or protein | Not Informative [formalin; in vitro; short duration; unknown exposure level relevance; small sample size; controls exhibited effects from air-only exposure]
(Persoz et al., 2012) | In vitro (human immortalized lung cells); n ≥3 experiments | Formalin gas: 0.050 mg/m^3^ for 30 min; treatment with sensitizers (i.e., TNFα or MCM) | Bronchial or alveolar cytokine secretion (at 24 hr post-FA) | IL-8 production in alveolar cells induced by TNFα or macrophage-conditioned media (MCM) increased by FA MCP-1 production in bronchial cells induced by sensitizers increased by FA N/C om IL-8 or MCP-1 otherwise; Note: expression affected by air alone | Not Informative [formalin; in vitro; short duration; unknown exposure level relevance; small sample size; controls exhibited effects from air-only exposure]
(Kastner et al., 2013) | In vitro (human immortalized lung cells); n = 3 experiments | Formalin gas: 0.2 mg/m^3^ for 30 min, 1 hr, or 2 hr/day once or for 4 d | Lung cell cytokine secretion and epithelial barrier function/viability (at 24 hr post-FA) | N/C in IL-6 or IL-8 release, or TEER (measures disruption to epithelial cell monolayer) by FA alone; Note: viability affected by air exposure | Not Informative [formalin; in vitro; short duration; unknown exposure level relevance; small sample size; controls exhibited effects from air-only exposure]
(Lino-Dos-Santos-Franco et al., 2013a) | Female Wistar rats (n = 5) | Formalin 1% or methanol vehicle for 3 d (90 min/ d), ± ovariectomy | BAL counts Ex vivo lung IL-10 | 1 d after challenge: FA/OVA versus OVA alone decreased total cell counts, including mononuclear cells, neutrophils, and eosinophils; FA/OVA versus OVA alone: Robust IL-10 increase | Not Informative [formalin (MeOH controls); naïve not chamber exposed; unquantified high levels; FA alone untested; small sample size]
(Lino-Dos-Santos-Franco et al., 2013a) | Female Wistar rats (n = 5) | Sensitization: After FA, s.c. 10 μg OVA, with s.c. boost 7 d later; Challenge: After 7 d, 1% OVA aerosol for 15 min | | 1 d after challenge: FA/OVA versus OVA alone decreased total cell counts, including mononuclear cells, neutrophils, and eosinophils; FA/OVA versus OVA alone: Robust IL-10 increase | Not Informative [formalin (MeOH controls); naïve not chamber exposed; unquantified high levels; FA alone untested; small sample size]
(Lino-Dos-Santos-Franco et al., 2010) | Male Wistar rats (n = 5–6) | Formalin 1% for 3 d (90 min/d) | Lung cellular oxidative burst (flow) and tissue oxidative stress-peroxynitrite (3-NT) | Increased cellular oxidative burst (DFFH, ± OVA); Increased lung nitration (peroxynitrite formation; without OVA) | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity]; Note: vitamin C, E blunted effects
(Lino-Dos-Santos-Franco et al., 2010) | Male Wistar rats (n = 5–6) | Sensitization: immediately post-FA, s.c. 10 μg OVA; boost 1 wk later with s.c. 10 μg OVA injection Challenge: 1 wk later with 1% aerosol OVA (15 min) | | Increased cellular oxidative burst (DFFH, ± OVA); Increased lung nitration (peroxynitrite formation; without OVA) | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity]; Note: vitamin C, E blunted effects
(Macedo et al., 2016a) | Male Wistar rats (n = 6) | Formalin 1% for 3 d (90 min/d) | Lung (or lung cells) oxidative stress increased H_2_O_2_ nitrites, oxidative burst, enzyme activity and gene expression of redox-related proteins | Formaldehyde exposure increased H_2_O_2_ and NO_2_, but not DCFH-DA (oxidative burst), and exposure increased expression of cNOS and iNOS, SOD and catalase, but did not affect the activity of enzymes associated with detoxification processes (e.g., glutathione reductase) | Not Informative [formalin; unquantified high levels; short duration and periodicity]; Note: Photobiomodulation (laser) therapy blunted effects
(Lima et al., 2015) | Male Fischer rats (n=7) | Formalin 1, 5, or 10% for 5 d (20 min × 3/d) | Trachea or diaphragm muscle (DM) oxidative stress indicators: carbonyl protein, lipid peroxidation, and catalase activity; and inflammatory cell influx | In Trachea: increased lipid peroxidation at 1 and 5, but not 10%; N/C in catalase or inflammatory cell influx; increased mucus deposits at 5%, and increased metaplasia and ulceration at 10%; In DM: increased lipid peroxidation at 1 and 5, but not 10%; increased carbonyl protein and increased inflammatory cell influx at 10%; decreased catalase at ≥1% | Not Informative [formalin; unquantified high levels; short duration and periodicity; controls not chamber exposed]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n = 5) | Formalin 0, 1% for 3 d (90 min/d) | BAL nitrites | FA increased BAL nitrites, which was exacerbated with OVA sensitization | NotInformative [formalin; unquantified high levels; small sample size; short duration and periodicity]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n = 5) | Sensitization: immediately post-FA, i.p. 10 μg OVA; boost 1 wk later with s.c. injection; Challenge: 1 wk later with aerosolized OVA | | FA increased BAL nitrites, which was exacerbated with OVA sensitization | NotInformative [formalin; unquantified high levels; small sample size; short duration and periodicity]
(Lino-Dos-Santos-Franco et al., 2013b) | Male Wistar rats (n = 5–8) | Formalin 1% or naive for 3 d (90 min/ d), with or without subsequent OVA | Lung mRNA Ex vivo Lung factors | FA increased iNOS and COX-1, but not COX-2, expression in lung (OVA and FA seemed to attenuate induction by other) FA/OVA vs. OVA increased NO and LTB_4_ (both inhibited by inhibition of NOS or by inhibition of COX), but not TXB_2_ or PGE_2_ Note: suggests mast cell- and NOmediated effects | NotInformative [formalin; unquantified high levels; small sample size; short duration and periodicity; comparisons reported did not include all relevant controls (e.g., FA alone; air alone)]
(Lino-Dos-Santos-Franco et al., 2013b) | Male Wistar rats (n = 5–8) | Sensitization: after FA inhalation, s.c. 10ug OVA with same boost 7 d later; Challenge: after 1 wk, 1% OVA aerosol for 15 min | | | NotInformative [formalin; unquantified high levels; small sample size; short duration and periodicity; comparisons reported did not include all relevant controls (e.g., FA alone; air alone)]
(Lino-Dos-Santos-Franco et al., 2011b) | Male Wistar rats (n = 5/group) | Formalin 1% for 3 d (90 min/d) | BAL cell counts Lung ROS Ex vivo lung cytokines in explants or cultured BAL cells | FA increased total BAL cells, mononuclear cells, and neutrophils; FA decreased SOD, but not catalase, GPX, GR, or GST activity in lung tissue; mRNA expression for SOD, catalase, NOS, and COX was increased; FA increased IL-1β and IL-6 in explants; increased NO_2_ and H_2_O_2_ in BAL cells | NotInformative [formalin; unquantified high levels; small sample size; short duration and periodicity; some ex vivo]
(Lino dos Santos Franco et al., 2006) | Male Wistar (n = 5–6) | Formalin 1% or methanol vehicle for 4 d (30, 60, or 90 min/d) | BAL cell counts Lung IHC Ex vivo BAL nitrites | Increased BAL Total cells (90 min only), mononuclear cells (60 and 90 min), and neutrophils (30, 60, or 90 min); Increased ex vivo cultured BAL cell release of nitrites; Lung IHC showed mast cell degranulation and neutrophil infiltration; Note: number of cells recovered in BAL was significantly reduced by capsaicin (depletes neuropeptides from sensory nerve endings), but bronchial hyporesponsiveness not altered; conversely L-NAME (inhibits NO synthase) did not affect BAL cells, but did restore bronchial responsiveness; administration of 48/80 to deplete mast cells blunted FA-induced effects on both BAL cell counts and bronchial response | Not Informative [formalin ((MeOH controls); unquantified high levels; small sample size; short duration and periodicity; comparisons reported to naïve rats rather than MeOH controls; some ex vivo]; NOTE: if a relevant MOA is identified from more informative studies, pharmacological intervention endpoints might be reconsidered
(Lino-Dos-Santos-Franco et al., 2011a) | Female Wistar rats (n = 5) | Formalin 1% or naïve for 3 d (90 min/d), with or without ovariectomy | BAL counts and mast cell degranulation | FA increased total BAL cell counts, mononuclear cells and neutrophils, but not eosinophils; Decreased lung mast cell number and increased degranulation | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity; impact of sham surgery/ FA alone untested; naïve not chamber exposed]
(Lino-Dos-Santos-Franco et al., 2010) | Male Wistar rats (n = 5–6) | Formalin 1% for 3 d (90 min/d) | Pulmonary vascular permeability (Evans blue); BAL cell counts Ex vivo cultured BAL cells factors/cytokines Phagocytosis (flow) | Increased BAL mononuclear cells and neutrophils, but N/C in eosinophils or in lung ICAM-1; Increased vascular permeability (± OVA) FA increased ex vivo LTB4; FA+OVA increased BAL LTB4, TXB2, IL-1b,Il-6,VEGF N/C in phagocytosis; | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity; some ex vivo]; Note: vitamin C and E blunted effects
(Lino-Dos-Santos-Franco et al., 2010) | Male Wistar rats (n = 5–6) | Sensitization: immediately post-FA, s.c. 10 μg OVA; boost 1 wk later with s.c. 10 μg OVA injection Challenge: 1 wk later with 1% aerosol OVA (15 min) | | | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity; some ex vivo]; Note: vitamin C and E blunted effects
(Kita et al., 2003) | Male Hartley guinea pigs (n = 10+/group) | Nasal Instillation of saline or Formalin 0.1 or 1.0%; 3×/wk for 6 wk s | BAL cell counts | N/C in BAL fluid cell counts by FA with passive or active sensitization (not measured for FA alone) | Not Informative [formalin; high, unknown levels; short periodicity; exposure route; effect of FA alone not measured]
(Kita et al., 2003) | Male Hartley guinea pigs (n = 10+/group) | Sensitization: intradermal anti-OVA serum on day 38 (passive) or i.p. 2 mg OVA on Day 3 (active) with boost i.p. 10 mg OVA day 24; Challenge: 1 mg/mL nebulized OVA 15 min after last FA exposure on day 45 | | N/C in BAL fluid cell counts by FA with passive or active sensitization (not measured for FA alone) | Not Informative [formalin; high, unknown levels; short periodicity; exposure route; effect of FA alone not measured]
(Kita and Oomichi, 1974) | In/Ex vitro: trachea from guinea pigs | Formalin gas: 39.4 or 67.7 mg/m^3^ for <30 min | In vitro ciliary beat frequency | FA decreased CBF 50% in 11.5 min (39.4 mg/m^3^) or 4.5 min (67.7 mg/m^3^) | Not Informative [formalin; excessively high levels; short duration; ex vitro; small sample size]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n=5) | Formalin 0, 1% for 3 d (90 min/d) | BAL cell counts Lung mast cell degranulation | Increased Total BAL cells, mononuclear cells, and neutrophils (eosinophils undetected); FA inhibited OVA-induced increases in all cell counts; FA increased mast cell degranulation; FA inhibited OVA induced degranulation FA induced PECAM expression; FA inhibited OVA induced increases | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n=5) | Sensitization: immediately post-FA, i.p. 10ug OVA; boost 1 wk later with s.c. injection; Challenge: 1 wk later 1% aerosol OVA for 15 min | | | Not Informative [formalin; unquantified high levels; small sample size; short duration and periodicity]

##### Changes in pulmonary function involving provocation

Table B-44 Changes in pulmonary function involving provocation (e.g., bronchoconstrictors; allergens; etc.)

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
[underlined: Observational Epidemiology Studies]
(Górski and Krakowiak, 1991) | Human textile and shoemakers (n = 367) | Not exceeding 0.5 mg/m^3^ (duration at least 1 year (average= ≈12 years) | Bronchial hyperreactivity to histamine | Bronchial hyperreactivity in 11 nonbronchitic patients (14 bronchitic/2 asthmatic ppl) | Low Confidence [incomplete and confusing methods and results; comparisons unclear]
[underlined: Controlled-Exposure Studies in Humans or Primary Human Cells]
(Krakowiak et al., 1998) | Human workers with bronchial asthma or healthy subjects (n = 10 each) | Formalin (assumed: test article NR): 0.5 mg/m^3^ for 2 hr with follow-up out to 24 hr | Bronchial provocation responses (histamine) | N/C in Bronchial reactivity to histamine (Note: scoring measures of nasal symptoms were elevated) | Low Confidence [formalin; short duration; small sample size]; NOTE: ACUTE; no effect on FEV_1_, etc.
(Casset et al., 2006) | Human (n = 19 with mild asthma and allergy to mite allergen) | Formalin ≈0.1 mg/m^3^ for 30 min; placebo at ≈0.03 mg/m^3^ double-blind randomized; restricted to mouth breathing only | Airway response to mite allergen (Note: large allergen size chosen to deposit in large airways) | A lower level of allergen was necessary to induce bronchoconstriction following FA exposure and FA exposure: both immediate and late-phase responses; note: N/C in pulmonary function tests with FA exposure alone prior to allergen challenge | Low Confidence [formalin; short duration; not clear that restriction to mouth breathing is realistic for typical inhalation]; NOTE: ACUTE; within-subjects comparison between air and FA
(Ezratty et al., 2007) | Human (n = 12 intermittent asthmatics with allergy to pollen) | Formalin 0.5 mg/m^3^ for 60 min; randomized to air or FA first (no nonexposed controls) | Allergen (pollen)-induced changes in airway FEV1 and MCh responses (note: did not appear to test MCh w/o allergen) 8 hr later | N/C in pulmonary function by allergen (a borderline decreased response, p = 0.06, was observed) or to MCh responsiveness after allergen challenge; note: N/C in pulmonary function by FA | Low Confidence [formalin; short duration]; NOTE: ACUTE; within subjects comparison between air and FA
[underlined: Controlled-Exposure Studies in Animals, Animal Cells, or Immortalized Human Cells]
(Riedel et al., 1996) | Female Dunkin-Hartley guinea pigs (n=12) | Formaldehyde (bottled pressurized gas) 0, 0.16, 0.31 mg/m^3^ for 5 d (8 hr/d) | Airway response to OVA | Increased OVA challenge-induced airway obstruction by 0.31 mg/m^3^ (3, 7, and 10 animals exhibited airway obstruction across groups) | High or Medium Confidence [no comparison group with FA without OVA]; NOTE: guinea pigs have been shown to be more sensitive to airway constriction from toxicants than other animals]
(Riedel et al., 1996) | Female Dunkin-Hartley guinea pigs (n=12) | Sensitization: 0.5% inhaled OVA; OVA boost at 2wk Challenge: 1% inhaled OVA 1 wk later | | Increased OVA challenge-induced airway obstruction by 0.31 mg/m^3^ (3, 7, and 10 animals exhibited airway obstruction across groups) | High or Medium Confidence [no comparison group with FA without OVA]; NOTE: guinea pigs have been shown to be more sensitive to airway constriction from toxicants than other animals]
(Leikauf, 1992) [considered same cohort as (Swiecichowski et al., 1993)] | Male Hartley guinea pigs (n = 5–7) | PFA 0, 0.12, 0.37, 1.23, 3.69, 12.3, or 36.9 mg/m^3^ for up to 8 hr | Bronchial reactivity to i.v. acetylcholine | Increased specific resistance at ≥12.3 mg/m^3^ with 2 hr; Increased at ≥1.23 mg/m^3^ with 8 hr (i.e., duration > concentration); with 8 hr, hyperreactivity persisted >24 hr postexposure | See Swiechichowski et al., 1993; NOTE: ACUTE
(Swiecichowski et al., 1993) | Male Hartley guinea pigs (n = 5–7/group) | PFA from 0.12–123 mg/m^3^, for 2 or 8 hrs (multiple experiments) | Airway reactivity Ex vivo airway reactivity (trachea) | Increased pulmonary resistance (reversible bronchoconstriction) and airway reactivity to acetylcholine at ≥1.23 mg/m^3^ (not at 0.36 mg/m^3^) for 8 hr; at ≥ 12.3 mg/m^3^ (not at ≤3.6 mg/m^3^) for 2 hr Increased ex vivo reactivity (smooth muscle contraction) at 4.18 mg/m^3^ for 8 hr | High or Medium Confidence at 1.23 mg/m^3^ and above [short duration]; Low Confidence below 1.23 mg/m^3^ and ex vivo [ex vivo; sample size of 5 at 1 or more levels below 1ppm]; NOTE: ACUTE; duration appeared to be more important than FA level for pulmonary resistance
(Larsen et al., 2013) | Male BALB/cA mice (n = 10) | PFA 0.49, 2.21, or 4.9-7.0 (dry vs. humid air) mg/m^3^; 60 min | Airway reactivity | Increased airway reactivity (decreased expiratory flow rate) in humid air in OVA-sensitized mice at 7 mg/m^3^; Increased bronchoconstriction in a dry environment without OVA sensitization at 4.92–7.0 mg/m^3^ (with OVA sensitization reducing the response to formaldehyde) | High or Medium Confidence [short duration]; NOTE: ACUTE; suggests that environmental humidity may affect acute airway reactivity induced by formaldehyde; experiments on inflammatory markers (below) considered less informative
(Larsen et al., 2013) | Male BALB/cA mice (n = 10) | Sensitization: pre-FA i.p. 1 μg OVA, with 0.1 μg OVA boosts i.p. on days 14 and 21 (note: FA on day 31) Challenge: 0.2% OVA aerosol- 20 min on day 29 and 30
(Liu et al., 2011) | Male Balb/c mice (n = 6/ group) | Formalin 0, 0.5, or 3 mg/m^3^ for 21 d (6 hr/d) | Airway reactivity | Slightly increased responsivity to MCh compared to saline controls; robust amplification in 3mg/m^3^ FA+OVA group | Low Confidence [formalin]
(Liu et al., 2011) | Male Balb/c mice (n = 6/ group) | Sensitization: i.v. 20 mg OVA on Days 10 and 21 Challenge: 1% OVA aerosol for 30 min/d for 7 d | | Slightly increased responsivity to MCh compared to saline controls; robust amplification in 3mg/m^3^ FA+OVA group | Low Confidence [formalin]
(Qiao et al., 2009) | Male Wistar rats (n = 8/group) | Formalin 0, 0.51 or 3.08 mg/m^3^ for 3 wk (6 hr/d) | Airway response to methylcholine | 3.08 mg/m^3^ FA alone increased hyperresponsiveness to MCh, which was amplified with OVA administration at ≥ 0.51 mg/m^3^ | Low Confidence [formalin]
(Qiao et al., 2009) | Male Wistar rats (n = 8/group) | Sensitization: i.p. OVA on Days 10 and 18 Challenge: 1% OVA 30 min/d for 7 d | | 3.08 mg/m^3^ FA alone increased hyperresponsiveness to MCh, which was amplified with OVA administration at ≥ 0.51 mg/m^3^ | Low Confidence [formalin]
(Wu et al., 2013) | Male Balb/c mice (n = 8/group) | Formalin 0, 3 mg/m^3^ for 4 wk (6 hr/d, 5 d/wk) | Airway responsivity to Methylcholine (MCh) | Airway was slightly hyperesponsive to MCh by FA alone, but severely so in FA+OVA groups; TRPA1 and TRPV1 antagonists reduced FA+OVA-induced airway responsiveness | Low Confidence [formalin; pharmacological interventions did not include effects of FA alone]
(Wu et al., 2013) | Male Balb/c mice (n = 8/group) | Sensitization: s.c. 80 μg OVA on Days 10, 18, and 25 Challenge: 1% OVA aerosol 30 min/d on Days 29–35 | | Airway was slightly hyperesponsive to MCh by FA alone, but severely so in FA+OVA groups; TRPA1 and TRPV1 antagonists reduced FA+OVA-induced airway responsiveness | Low Confidence [formalin; pharmacological interventions did not include effects of FA alone]
(Biagini et al., 1989) | Male cynomolgus monkeys (n = 9) | Formalin 3.08 mg/m^3^ for 10 min (challenge experiment) | Bronchoreactivity to methylcholine (all with MCh) | Increased bronchoconstriction by FA challenge at 2, 5, and 10 min postchallenge | Low Confidence [formalin; short duration; FA without methylcholine untested]
(Maiellaro et al., 2014) | Pregnant Wistar rats (n = 5) | Formalin 0.92 mg/m^3^ from GDs 1–21: 1 hr/d, 5 d/wk | Tracheal response to MCh | 24 hr after OVA challenge, offspring have: decreased tracheal response to MCh; Note: Decreased birth weight in offspring. Nonmanipulated group exhibits large, unexplained differences from vehicle control (and has reporting limitations) | Not Informative [formalin; short periodicity; offspring comparisons do not include FA alone; unclear comparability for some groups; small sample size]
(Maiellaro et al., 2014) | Pregnant Wistar rats (n = 5) | Sensitization: s.c. 10 μ g OVA with sc boost after 7 d Challenge: 7 d later, 1% OVA aerosol 15 min/d, 3 d | | | Not Informative [formalin; short periodicity; offspring comparisons do not include FA alone; unclear comparability for some groups; small sample size]
(Silva Ibrahim et al., 2015) | Pregnant Wistar rats (n = 5 dams; 10 pups/ group for experiments) | Formalin 0.92 mg/m3 from GDs 1–21: 1 hr/d, 5 d/wk | Response to MCh | 24 hr after LPS challenge, offspring exposed to formaldehyde have decreased MCh response | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size]
(Silva Ibrahim et al., 2015) | Pregnant Wistar rats (n = 5 dams; 10 pups/ group for experiments) | Randomly assigned pups all received 5 mg/kg lipopolysacharride (LPS) injections at PND 30 | | 24 hr after LPS challenge, offspring exposed to formaldehyde have decreased MCh response | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size]
(Kita et al., 2003) | Male Hartley guinea pigs (n = 5–7/group) | Nasal Instillation of saline or Formalin 0.1 or 1.0%; 3×/wk for 6 wk | Bronchoconstriction to methylcholine | N/C in airway response to MCh by FA or FA with passive sensitization, but induced by FA with active sensitization | Not Informative [formalin; high, unknown levels; short periodicity; exposure route]
(Kita et al., 2003) | Male Hartley guinea pigs (n = 5–7/group) | Sensitization: intradermal anti-OVA serum on day 38 (passive) or i.p. 2 mg OVA on day 3 (active) with boost i.p. 10 mg OVA Day 24; Challenge: 1 mg/mL nebulized OVA 15 min after last FA exposure on Day 45 | | N/C in airway response to MCh by FA or FA with passive sensitization, but induced by FA with active sensitization | Not Informative [formalin; high, unknown levels; short periodicity; exposure route]
(Lee et al., 1984) | Male English guinea pigs (n = 4) | Formalin: 7.38 or 12.3 mg/m^3^ for 5 d; FA challenge with 2.46 or 4.9 mg/m^3^ for 1 or 4 hr, respectively on Days 7, 22, and 29; Respiratory rate change from prechallenge baseline | | N/C in pulmonary sensitivity (either immediate or delayed-onset) to formaldehyde challenge; Note: 2/4 animals exhibited dermal sensitivity (likely contact-mediated) to topical FA; 12.3 mg/m^3^ caused 40–50% respiratory rate decrease for ≥5 hr (later time points NR) | Not Informative [formalin; small sample size; high exposure levels; no comparison to controls with no prior formaldehyde exposure (unclear if this, by itself, caused effects); unclear reporting]
(Lino-Dos-Santos-Franco et al., 2013a) | Female Wistar rats (n = 5) | Formalin 1% or methanol vehicle for 3 d (90 min/d), ± ovariectomy | Lung oxidative stress, microvascular leakage and mast cell degranulation; ex vivo tracheal reactivity | 1 d after OVA challenge: FA/OVA versus OVA alone: Reduced MPO and vascular permeability; decreased mast cell degranulation; Decreased tracheal reactivity | Not Informative [formalin (MeOH controls), naïve not chamber exposed; high. unquantified levels, FA alone untested; small sample size]
(Lino-Dos-Santos-Franco et al., 2013a) | Female Wistar rats (n = 5) | Sensitization: After FA, s.c. 10 μg OVA, with s.c. boost 7 d later; Challenge: After 7 d, 1% OVA aerosol for 15 min | | 1 d after OVA challenge: FA/OVA versus OVA alone: Reduced MPO and vascular permeability; decreased mast cell degranulation; Decreased tracheal reactivity | Not Informative [formalin (MeOH controls), naïve not chamber exposed; high. unquantified levels, FA alone untested; small sample size]
(Lino-Dos-Santos-Franco et al., 2011a) | Female Wistar rats (n = 5) | Formalin 1% or naïve for 3 d (90 min/d), with or without ovariectomy | Ex vivo trachea response | N/C in ex vivo tracheal response to methacholine | Not Informative [formalin, naïve not chamber exposed; ex vivo; high, unquantified levels, FA alone untested; small sample]
(Lino dos Santos Franco et al., 2006) | Male Wistar (n = 5–6) | Formalin 1% or methanol vehicle for 4 d (30, 60, or 90 min/d) | Ex vivo airway responsivity | Decreased ex vivo bronchial, but not tracheal, response to methacholine Note: number of cells recovered in BAL was significantly reduced by capsaicin (depletes neuropeptides from sensory nerve endings), but bronchial hyporesponsiveness not altered; conversely L-NAME (inhibits NO synthase) did not affect BAL cells, but did restore bronchial responsiveness; administration of 48/80 to deplete mast cells blunted FA-induced effects on both BAL cell counts and bronchial response | Not Informative [formalin (MeOH controls); naïve not chamber exposed; high, unquantified levels, comparisons to naïve rats rather than MeOH controls; small sample size]; NOTE: if a relevant MOA is identified from more informative studies, pharmacological intervention endpoints might be reconsidered
(Lino-Dos-Santos-Franco et al., 2013b) | Male Wistar rats (n = 5–8) | Formalin 1% or naive for 3 d (90 min/d), with or without subsequent OVA | Ex vivo bronchial response to MCh | Prior FA exposure reduced OVA-induced ex vivo bronchial hyperresponsiveness Note: N/C in respiratory resistance or elastance with FA alone | Not Informative [formalin; naïve not chamber exposed; high, unquantified levels; short duration and periodicity; comparisons did not include all relevant controls (e.g., FA alone; air alone); small sample size]
(Lino-Dos-Santos-Franco et al., 2013b) | Male Wistar rats (n = 5–8) | Sensitization: after FA inhalation, s.c. 10 μg OVA with same boost 7 d later; Challenge: after 1 wk, 1% OVA aerosol for 15 min | | Prior FA exposure reduced OVA-induced ex vivo bronchial hyperresponsiveness Note: N/C in respiratory resistance or elastance with FA alone

#### Evaluation of Mechanistic Evidence Related to Changes in the Blood or Lymphoid Organs

##### Changes in serum (primarily) antibody responses

Table B-45 Serum (primarily) antibody responses

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
[underlined: Observational Epidemiology Studies]
(Wantke et al., 1996a) | Human children in schools (n = 62) vs. control (n = 19) | Particleboard schools: 0.053, 0.085, or 0.092 mg/m^3^ (n = 18, 22, 22); brick schools: 0.036, 0.028, or 0.032 mg/m^3^ (n=18, 22, 22); unclear duration (<2.5 year) | Serum FA-specific IgE | Before switching schools, 40% of students had elevated FA-specific IgE, which significantly decreased 3 mos after switch to low-FA schools (p <0.002); Note: while symptoms correlated to FA levels, FA-specific IgE did not | High or Medium Confidence [no blinding, but not clearly an issue]; Note: Natural experiment (pre- and postschool switch) with limited exposure contrast and assays
(Kim et al., 1999) | Human medical students (n = 167) and nonexposed controls (n = 67) | 3.74 ± 3.48 mg/m^3^ for up to 4 years of school (periodicity NR) | Serum FA-specific IgG and IgE (antibodies to FA-human serum albumin conjugate) | 14 (8.4%) students had FA-specific IgG, which was not related to duration of schooling (No relationship to symptoms) N/C in FA-specific IgE | High or Medium Confidence Note: Limited assays
(Aydın et al., 2013) | Human male fiberboard workers | 0.25 ± 0.074 mg/m^3^ (average 7.3 year employed; n = 46) vs. nonexposed controls | Serum Antibodies | Decreased IgG and IgM N/C in IgA | High or Medium Confidence
(Wantke et al., 1996b) | Human medical students (n = 45) | 0.153± 0.062 mg/m^3^ for 4 wk (Total: 17 d; 51 hr); phenol co-exposure | Serum FA-specific IgE Total IgE | N/C in FA-specific IgE; N/C in total IgE | Low Confidence [37% participation; phenol co-exposure; limited periodicity]; Note: limited assays
(Wantke et al., 2000) | Human medical students (n = 27); 23 controls | 0.265± 0.07 mg/m^3^ for 5 or 10 wks (intermittent—not specified, but assumed ≈3 hr/d) | Serum Antibodies and FA-specific Antibodies | After 5 wk: N/C FA-IgE or Total IgE After 10 wk: 4/27 students developed IgE against FA-albumin, but 0/23 developed IgG; N/C in Total IgE | Low Confidence [no reporting of % participation or population demographics; limited, unclear periodicity; phenol co-exposure]; Note: 1 of 4 positive was a smoker (4 smokers in study); limited assays
(Erdei et al., 2003) | Human (sex NR) symptomatic students (9–11 yow/ respiratory issues) (n = 176) | 0.006–0.057 mg/m^3^ (average = 0.018 mg/m^3^); duration unknown [coexposure: NO_2_, benzene, toluene, xylene, and dust mite allergen] | Serum Antibodies | N/C total IgG, IgA, IgM, or IgE (data NR) Increased airway pathogen bacteriaspecific IgG (not IgA or IgM) with FA | Low Confidence [comparisons to “normal” range rather than to control group; co-exposure; limited reporting]; Note: symptomatic only; authors hypothesized increased bacterialspecific IgG may represent increased B cell response (maybe more infections)
(Zhou et al., 2005) | Human anatomy students (n = 8) | 0.74 ± .11 mg/m^3^ (4-wk course—intermittent) | Serum FA-specific IgE antibodies | No students had FA-specific IgE after exposure | Low Confidence [small sample (n=8); limited, unclear periodicity; reporting as yes/no rather than analytical results, and no clear comparison to preexposure]
(Ohmichi et al., 2006) | Human anatomy students (n = 8 measured for FA; n = 6 for FA-specific IgE) | 0.41–1.81 mg/m^3^ (20 laboratory sessions over 10 wks; laboratory sessions ranged from 1.1–10 hrs, averaging 3hr) | Serum IgE and FA-specific IgE (threshold of 0.34 UA/mL) | No significant changes in IgE, and no positive result for FA-specific IgE (data presented was highly variable), as compared to measure 90 min before 1^st^ session of laboratory course | Low Confidence [small sample (n=6–8); limited and variable periodicity]
(Thrasher et al., 1987) | Human sympto-matic exposed subjects, controls (n = 8/ group) | Exposed (mobile home measures): 0.086–0.68 mg/m^3^ (residency ≈6–7 year); nonexposed: not measured (authors assume: <0.037) | Serum FA-specific IgG and IgE | No detection of FA-specific IgE Increased FA-specific IgG in all 8 exposed subjects, but only in 1/8 controls (had PD) | Low Confidence [small sample; symptomatic vs. nonsymptomatic comparison; reporting limitations]
(Dykewicz et al., 1991) | Human medical volunteers (n = 55; 31 F, 24 M) | Generally, 0.25–0.79 mg/m^3^ (1 subject up to 13.5 mg/m^3^); duration 4.53 ± 1.09 year | Serum FA-specific IgG and IgE | N/C in incidence of FA-HSA- specific IgG or IgE (3 subjects had FA-specific IgG and IgE, and 2 more had FA-specific IgG only) | Low Confidence [periodicity unspecified; unclear exposure comparison- control levels NR and variable range in exposed]
(Thrasher et al., 1990) | Human various exposed groups of patients, and asymptomatic controls | “controls”—chiropractic students (n = 28): assumed ≥ 0.53 mg/m^3^ for 28 wk (13 hr/wk); mobile home residents (n = 19): 0.05–0.62 mg/m^3^ for 2–7 year; office workers (n = 21): assumed 0.012–0.95 mg/m^3^, duration N/R; occupational (n = 8): levels/ duration N/R; removed from exposure for ≥1 year: 0.17–1.0 mg/m^3^ | Serum FA-specific IgG, Blood autoantibodies | Proportion of pooled titers (IgG, IgM, and IgM, and IgE IgE) of FA-specific antibodies (i.e. % at ≥ 1:8) was greater in all patient groups than in controls (Note: most apparent for IgG, but others also appear elevated; FAspecific IgE was not found in any of the patients “removed” from exposure) Mobile home residents and office workers had increased autoantibodies vs. controls (i.e., antismooth muscle or antiparietal cell) | Low Confidence [controls not unexposed; patients to nonpatients comparisons questionable]; Note: authors argue only real difference between asymptomatic control students and patients is one of duration of exposure
(Górski and Krakowiak, 1991) | Human textile and shoe makers (n = 367) | Not exceeding 0.5 mg/m^3^ (duration at least 1 year (average ≈12 years) | Serum FA-specific IgE Antibodies | No FA-specific IgE in patients tested (seems to be testing in a small subset of all subjects) | Low Confidence [incomplete and confusing methods and results; comparisons unclear]
Palczynski et al., 1999) | Human apartment residents (n = 465 total, ≈40% children) | 3 categories of exposure: <0.025, 0.025–0.05, and >0.0501 mg/m^3^; duration unclear, periodicity assumed to be constant | Total serum IgE Note: N = 1–2 at high HCHO levels; N = 27–38 at mid, low levels Serum antibodies to FA | Total IgE was not changed at 0.025–0.5 as compared to <0.025 in children or adults (n size at >0.05 was too small to compare); No FA-specific antibodies were detected (details NR); note: children exposed to 0.025–0.05 mg/m^3^ and tobacco smoke had elevated IgE | Low Confidence: IgE [small sample size; subsampling for IgE not reported; minimal exposure differential; results not stratified by sex or smoking status]; Not Informative: FA antibodies [methods NR; data NR]
(Madison et al., 1991) | Human residents, spill-exposed (n = 41) or unexposed controls (n = 29) | Formaldehyde (PFA): >2.46 mg/m^3^ for first 48 hr, then average dropped to 0.028 mg/m^3^, but urea and methylamines unmeasured/not corrected | FA-specific serum antibodies and autoantibodies | N/C in FA-specific IgE Increased FA-specific IgM and IgG Increased odds ratio of having 1+ autoantibodies (although higher, no sig. increase in any one auto-antibody) | Not Informative [mixture exposure; co-exposures not corrected for; FA in controls unmeasured]
(Grammer et al., 1990) | Human workers (Boeing; n = 37); details N/R | 0.0037–0.090 mg/m^3^ (not stratified by exposure; all exposed; duration N/R) | Serum FA-specific IgG and IgE | 0/37 had FA-specific IgG 5/37 had elevated IgE (vs. control sera) that was not specific to FA-HSA or HSA | Not Informative [details on population N/R; details on exposure NR; no specific comparison to FA levels]
[underlined: Controlled-Exposure Studies in Animals, Animal Cells, or Immortalized Human Cells]
(Fujimaki et al., 2004b) | Female C3H mice (n = 5–6 per group) | PFA 0, 0.098, 0.49, or 2.46 mg/m^3^; 12 wks (16 hr/d, 5 d/wk) | Serum Antibodies and Antibodies to Antigen | No change in anti-OVA IgE (variable) or IgG_2a_ or Total IgE Decreased anti-OVA IgG_1_ (at 0.49 mg/m^3^ only) and IgG_3_ (at 0.098–0.49 mg/m^3^) Body weight decreased 20% at 0.49 mg/m^3^ | High or Medium Confidence [slightly small sample size]
(Fujimaki et al., 2004b) | Female C3H mice (n = 5–6 per group) | Sensitization: i.p. 10 μg OVA prior to FA exposure; aerosol OVA boost for 6 min on wks 3, 6, 9, and 11 | | No change in anti-OVA IgE (variable) or IgG_2a_ or Total IgE Decreased anti-OVA IgG_1_ (at 0.49 mg/m^3^ only) and IgG_3_ (at 0.098–0.49 mg/m^3^) Body weight decreased 20% at 0.49 mg/m^3^ | High or Medium Confidence [slightly small sample size]
(Riedel et al., 1996) | Female Dunkin-Hartley guinea pigs (n = 12) | Formaldehyde (bottled pressurized gas) 0, 0.13, 0.31 mg/m^3^ for 5 d (8 hr/d); | Serum OVA-specific IgG1 | Increased OVA-specific IgG1 by 0.31 mg/m^3^ | High or Medium Confidence [no comparison group with FA without OVA]
(Riedel et al., 1996) | Female Dunkin-Hartley guinea pigs (n = 12) | Sensitization: 0.5% inhaled OVA; OVA boost at 2 wk Challenge: 1% inhaled OVA 1 wk later | | Increased OVA-specific IgG1 by 0.31 mg/m^3^ | High or Medium Confidence [no comparison group with FA without OVA]
(Sapmaz et al., 2015) | Male SD rats (n = 5–7) | PFA 0, 6.15, 12.3 mg/m^3^; 4 wks (8 hr/d, 5 d/wk) | Serum Antibodies | Increased IgA, IgM, and complement 3 Decreased IgG | High or Medium Confidence [slightly small sample size; high formaldehyde levels]
(Tarkowski and Gorski, 1995) | Female Balb/c mice (n = 4/ group) | Formalin (assumed; test article N/R) 0 or 2 mg/m^3^ for 10 d (6 hr/d) or 7 wk (6 hr/d, 1 d/wk) | Serum OVA-specific IgE | Increased OVA-specific IgE in mice exposed for 10 d, but not in those exposed 1x/ wk, as compared to controls Specific to nasal tissue, as OVA sensitization via i.p. injection caused N/C | Low Confidence [formalin; small sample size]; Note: pinpoints issue of importance and interpretability of different sensitization methods
(Tarkowski and Gorski, 1995) | Female Balb/c mice (n = 4/ group) | Sensitization: intranasal 25 μg OVA 1x/wk for 7 wk OR i.p. 1 μg OVA 1×/wk for 4 wk | | Increased OVA-specific IgE in mice exposed for 10 d, but not in those exposed 1x/ wk, as compared to controls Specific to nasal tissue, as OVA sensitization via i.p. injection caused N/C | Low Confidence [formalin; small sample size]; Note: pinpoints issue of importance and interpretability of different sensitization methods
(Wu et al., 2013) | Male Balb/c mice (n = 8/group) | Formalin 0, 3 mg/m^3^ for 4 wk (6 hr/d, 5 d/wk) | Serum antibodies | FA alone increased total IgE, but not OVAIgG or OVA-IgE; FA+OVA increased IgE compared to OVA alone, but did not further elevate OVA-IgG or OVA-IgE (slight, NS increases) compared to OVA TRPA1 and TRPV1 antagonists reduced FA+OVA-induced serum antibodies | Low Confidence [formalin; pharmacological interventions did not include effects of FA alone]
(Wu et al., 2013) | Male Balb/c mice (n = 8/group) | Sensitization: s.c. 80 μg OVA on Days 10, 18, and 25 Challenge: 1% OVA aerosol 30 min/d on Day 29-35 | | | Low Confidence [formalin; pharmacological interventions did not include effects of FA alone]
(Kim et al., 2013b) | Female NC/Nga (atopic-prone) mice (n = 5– 7/group) | Formalin (assumed; test article NR) 0, 0.25, 1.23 mg/m^3^ for 4 wk (6 hr/d, 5 d/wk) | Plasma Antibodies and Antigen-specific Abs | Plasma IgG1 increased by FA alone (0.25 mg/m^3^ only), but N/C in total IgE or IgG2a FA exacerbates HDM-induced IgE (≥0.25 mg/m^3^) and IgG2a (0.25 mg/m^3^ only), but not IgG1 HDM-specific IgE not changed | Low Confidence [formalin; small sample size]; Note: multiple supplementary files; [underlined: HDM-specific IgE data NR]
(Kim et al., 2013b) | Female NC/Nga (atopic-prone) mice (n = 5– 7/group) | Sensitization: topical house dust mite (HDM; ear) stimulation (25 mg Df ointment) 1×/wk for 4 wk | | | Low Confidence [formalin; small sample size]; Note: multiple supplementary files; [underlined: HDM-specific IgE data NR]
(Gu et al., 2008) | Female Balb/c mice (n = 5–6/group) | Formalin (assumed; test article NR) 0.12 or 0.98 mg/m^3^ for 5 wk (24 hr/d, 5 d/wk) | Serum Antibodies and OVA-specific Antibodies | N/C in total serum IgG or IgE Increased OVA-specific IgE in allergen primed host, only at 5 wks (not ≤ 4 wk) and only at 0.98 mg/m^3^; N/C in OVA-IgG | Low Confidence [formalin; small sample size]
(Gu et al., 2008) | Female Balb/c mice (n = 5–6/group) | Sensitization: i.p. 10 mg OVA on day 0 and 7 pre-FA | | N/C in total serum IgG or IgE Increased OVA-specific IgE in allergen primed host, only at 5 wks (not ≤ 4 wk) and only at 0.98 mg/m^3^; N/C in OVA-IgG | Low Confidence [formalin; small sample size]
(Jung et al., 2007) | Female C57BL/6 mice (n≥5/ group) | Formalin (assumed; test article NR) 0, 6.15, 12.3 mg/m^3^ for 2 wk (6 hr/d, 5 d/wk) | Serum Antibodies | Increased Total IgG1, IgG3, IgA, and IgE Decreased Total IgG2a and 2b; N/C IgM Note: body wt decreased ≈10% | Low Confidence [formalin; high
(Holmstrom et al., 1989a | Female SD rats (n = 8–9 treated rats; n = 6 control) | Formalin (assumed; test article NR) 15.5 ± 2.3 mg/m^3^ for 22 mos (6 hr/d, 5 d/wk); all rats vaccinated: anti-tetanus and Pneumovax | Serum antibody response to vaccination | N/C in IgM response to vaccine-related antigens; Variable increases in IgG against specific antigens were not statistically significant (Note: IgE not measured) | Low Confidence [formalin; excessively high exposure level; no unvaccinated comparison group]; Note: authors indicate B cell function unchanged
(Lee et al., 1984) | Male English guinea pigs (n = 4) | Formalin: 7.38 or 12.3 mg/m^3^ for 5 d, with FA challenge with 2.46 or 4.9 mg/m^3^ for 1 or 4 hr, respectively | Serum antibody to formaldehyde (isotype not specified) measured 9 or 17 d (i.e., Days 14 or 22) after exposure | N/C antibody response to 2.46 or 4.9 mg/m^3^ (data NR); Note: 2/4 animals exhibited dermal sensitivity (likely contact-mediated) to topical FA | Low Confidence [formalin; small sample size; high exposure levels]; Note: although there was no comparison to controls with no prior formaldehyde exposure, this is not expected to affect this measure
(Sadakane et al., 2002) | Male ICR mice (n = 9 or 18) | Formalin 0.5% for 4 wk (15 min/wk) ± sensitization of house dust mite allergen (Der f) | Blood Der f-specific IgG1 and IgE | N/C in Der f-specific IgG1 or IgE (latter appears to have been lower than detection limit) | Low Confidence [formalin; high, unknown exposure levels; short periodicity]
(Sadakane et al., 2002) | Male ICR mice (n = 9 or 18) | Sensitization: i.p. with 3 mg/mL Der f (house dust mite allergen) prior to FA Challenge: intratracheal 10 μg Der f 3 hr after last exposure (note: measures 3 d later) | | N/C in Der f-specific IgG1 or IgE (latter appears to have been lower than detection limit) | Low Confidence [formalin; high, unknown exposure levels; short periodicity]
Kita et al., 2003) | Male Hartley guinea pigs (n = 57/group) | Nasal Instillation of saline or Formalin 0.1 or 1.0%; 3×/wk for 6 wk | PCA reaction of naïve animals to injected serum of exposed animals | Increased anti-OVA IgG at ≥0.1% FA (at 4 hr, but not 7 d after OVA challenge) in naïe animals injected with serum | Not Informative [exposure route; formalin; high, unknown exposure levels; short periodicity; small sample size (for some endpoints/ groups)]
Kita et al., 2003) | Male Hartley guinea pigs (n = 57/group) | Sensitization: i.p. anti-OVA serum on after 5 wk FA (passive) or i.p. 2 mg OVA on day 3 (active) prior to FA exposure with boost i.p. 10 mg OVA Day 24 Challenge: 1 mg/mL nebulized OVA 15 min after last FA exposure on Day 45 | | Increased anti-OVA IgG at ≥0.1% FA (at 4 hr, but not 7 d after OVA challenge) in naïe animals injected with serum | Not Informative [exposure route; formalin; high, unknown exposure levels; short periodicity; small sample size (for some endpoints/ groups)]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n = 5) | Formalin 0, 1% for 3 d (90 min/ d) | Skin Antibodies | N/C in skin IgE | Not Informative [formalin; unquantified high exposure levels; small sample size; short duration and periodicity]; Note: unclear endpoint relevance
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n = 5) | Sensitization: immediately post-FA, i.p. 10 μg OVA; boost 1 wk later with s.c. injection Challenge: 1 wk later with aerosolized OVA | | N/C in skin IgE | Not Informative [formalin; unquantified high exposure levels; small sample size; short duration and periodicity]; Note: unclear endpoint relevance
(Lino-Dos-Santos-Franco et al., 2013a) | Female Wistar rats (n = 5) | Formalin 1% or methanol vehicle for 3 d (90min/d), ± ovariectomy | Skin IgE | 1 d after OVA challenge: FA/OVA vs. OVA alone: N/C in cutaneous OVA-specific IgE | Not Informative [formalin (MeOH controls); unquantified high exposure levels; small sample size; short duration and periodicity; naïve not chamber exposed]; Note: unclear endpoint relevance
(Lino-Dos-Santos-Franco et al., 2013a) | Female Wistar rats (n = 5) | Sensitization: After FA, s.c. 10 μg OVA, with s.c. boost 7 d later Challenge: After 7 d, 1% OVA aerosol for 15 min | | 1 d after OVA challenge: FA/OVA vs. OVA alone: N/C in cutaneous OVA-specific IgE | Not Informative [formalin (MeOH controls); unquantified high exposure levels; small sample size; short duration and periodicity; naïve not chamber exposed]; Note: unclear endpoint relevance

##### Serum markers of immune response (other than antibodies), inflammation, or oxidative stress

Table B-46 Serum markers of immune response (other than antibodies), inflammation, or oxidative stress

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
Observational Epidemiology Studies
(Aydın et al., 2013) | Human male fiberboard workers | 0.25 ± 0.074 mg/m^3^ (average 7.3 year employed; n = 46) vs. nonexposed controls | Serum cell counts, cytokines, and related factors | N/C in # hematologic cells, WBC, RBC, Hb, neutrophils, or monocytes; N/C in helper T, suppressor T, or B lymphocytes Increased % of lymphocytes, and numbers and % of T cell (CD3+) and NK cell (CD56+) Increased TNFα, but N/C in Complement 3 or 4; TNFα increased more significantly in those not using protective measures | High or Medium Confidence Note: annex reviews immune data
(Bassig et al., 2016) (same cohort as (Zhang et al., 2010) | Human melamine workers (n = 43) or n = 51 age- and sex-matched unexposed from different factories in the same region of China | 1.6 mg/m^3^ (10% and 90% = 0.74 and 3.08 mg/m^3^); unclear exposure duration (sampling over a 3-wk period) | Serum cell counts and soluble markers | Decreased total WBC, Granulocytes, Monocytes, Platelets, and Lymphocytes Decreased CD8+ cells (CD8 effector memory cells most affected) and NK cells N/C in Monocytes, CD4+ cells, CD4/CD8 ratio, or B cells; N/C in soluble CD27 or CD30 | High or Medium Confidence
(Costa et al., 2013) | Human pathology anatomists (n = 35) or administrative controls (n = 35) | 0.44 ± 0.037 mg/m^3^ (as high as 0.85 mg/m^3^ in peaks); duration of employment ≥ 1year | Serum lymphocyte subtypes | Decreased B cells (% CD19+) in exposed N/C in T cells or NK cells in exposed Within the exposed workers: FA exposure level correlated with Increased % T cells (CD3+) and % T helper cells (CD4+), and decreased % NK cells | High or Medium Confidence Note: authors suggest immunosuppression
(Costa et al., 2019) | Human anatomy-pathology lab workers (n = 85) or administrative controls (n = 87) | 8 hr TWA=0.47 ± 0.037 mg/m^3^ (range = 0.098–1.71 mg/m^3^; as high as 3.94 mg/m^3^ in peaks); duration of employment average ≈12 year | Serum lymphocyte subtypes | Increased Cytotoxic (CD8+) T cells and NK cells; Decreased B cells and CD4/CD8 ratio; N/C in total T cells or Helper (CD4+) T cells | High or Medium Confidence Note: authors suggest immunostimulation
(Zhang et al., 2010) | Human formaldehyde melamine workers | 51 Controls: <0.037 mg/m^3^; 43 Exposed: 1.8 (0.42–6.9) mg/m^3^; Duration at least 3 mos (41/43 exposed > 1 year) | Serum immune markers | 22/38 immune/inflammation markers that were detectable were decreased Stringent FDR cutoff (10%): significantly decreased CXCL11 and CCL17 (both ≈25%) FDR at 20%: significantly decreased CRP, TRAIL, SAP, IL-10, sCD40L, and Insulin N/C in TNF-a; other markers below LOD | High or Medium Confidence [Note: the strongest correlation of marker changes was with monocyte levels (p = 0.05), but overall the results suggest that cell counts do not explain the marker changes]
(Zhang et al., 2010) | Human formaldehyde melamine workers | 51 Controls: <0.037 mg/m^3^; 43 Exposed: 1.57 (0.77–6.9) mg/m^3^; Duration at least 3 mos (41/43 exposed > 1 year) | Serum cell counts Proliferation of serum hematopoietic progenitor cells | Decreased WBC, lymphocytes, granulocytes, platelets, and RBC Increased mean corpuscular volume N/C in monocytes, hemoglobin Decreased colony formation in cultured hematopoietic progenitors from subjects | High or Medium Confidence [one ex vivo endpoint: possible influence of culturing- still expected to be due to exposure, but could involve in vitro amplification of phenomena]
(Jia et al., 2014) | Human plywood workers (n = 118) and controls (n = 79) | [High] workers: 0.77 (0.44–1.88) mg/m^3^ (n = 70); [Low] workers: 0.18 (0.086–0.23) mg/m^3^ (n = 48); duration ≥6 mos; controls <0.01 mg/m^3^ | Serum lymphocyte subtypes and cytokines | Dose-dependent increased % CD19+ B cells at ≥ 0.18 mg/m^3^; increased CD56+ NK cells at 0.18 mg/m^3^ only N/C in %CD3+, CD4+ or CD8+ T cells Increased IL-10 and decreased IL-8 at ≥ 0.18 mg/m^3^; Increased IL-4 and decreased IFNγ at 0.77 mg/m^3^ | High or Medium Confidence
(Hosgood et al., 2013) Note: Same cohort as (Zhang et al., 2010) | Human formaldehyde melamine workers | 51 Controls: 0.032 (0.01–0.032) mg/m^3^; 43 Exposed: 1.57 (0.77–3.09) mg/m^3^; Duration at least 3 mos (41/43 exposed >1 year) | Serum counts and analyses of lymphocyte subsets. | Decreased lymphocytes, NK cells, T cells, and CD8+ T cells; N/C in B cells, or CD4+ T cells (overall; note: CD4+/FoxP3+ decreased); T cells subset analyses showed decreased CD8+ effector T cells and regulatory T cells | High or Medium Confidence; Note: Authors hypothesized decreased effector T cells (which circulate to inflamed tissues) may reflect decreased response to antigenic-related inflammation, and decreased regulatory cells as decreased immunosuppression (which may lead to autoimmunity)
(Ye et al., 2005) | Human students (n = 23), waiters (n = 16), or FA manufacturers (n = 18) | [High] Manufacturers: 0.98 5 ± 0.286 mg/m^3^ (8.5 year, 8 hr/d; 1.69 maximum); [Low] waiters: 0.107 ± 0.067 mg/m^3^ (12 wk, 5 hr/d); Controls: 0.015 mg/m^3^ | Blood lymphocyte subset analysis | N/C in waiters exposed to low levels.; Increased % B cells and ratio of T helper to T cytotoxic T cells (CD4/CD8 ratio), and decreased total T cells and CD8+ T cells in workers exposed to high levels | High or Medium Confidence [data not adjusted for age or gender]
(Bono et al., 2010) | Human pathologists (n = 44) and controls (n = 32) | Controls: 0.028 ± 0.0025 mg/m^3^; Pathologists: 0.032 ± 0.006 or 0.21 ± 0.047 mg/m^3^ (in “reduction room”); duration unclear | Serum lymphocyte ROS (MDA-dG adducts) | Increased MDA-dG at > 0.066 mg/m^3^; N/C in MDA-dG at <0.022 mg/m^3^ or 0.023–0.066 mg/m^3^ (significant association with air-FA levels) | High or Medium Confidence (unknown duration)
(Romanazzi et al., 2013) | Human Laminate workers (males, years employed NR) | 0.21 ± 0.10 mg/m^3^ exposed (n = 51); 0.04 ± 0.02 mg/m^3^ nonexposed (n = 54) | 15-F_2t_ Isoprostanes in urine (also measured cotinine and smoking) | Smoking and air-formaldehyde exposure were independently associated with increased IsoP | High or Medium Confidence - indirect [accuracy of single measure questionable] Note: serum and urine isoprostanes are correlated (Rodrigo et al., 2007); thus, this finding is indirect for serum ROS
(Lyapina et al., 2004) | Human workers with carbamide-FA glue (n = 29) | Exposed workers: 0.87 ± 0.39 mg/m^3^ (n = 21 nonexposed); duration mean: 12.7 ± 9.6 years | Blood neutrophil oxidative burst Routine hematology Assessment of chronic URT inflammation | Significant decreases in neutrophil function/oxidative burst were only detected when comparing the 12 workers with evidence of URT inflammation (N/C across full groups); Decreased erythrocyte count and hematocrit levels correlated with duration of exposure (no other changes) | High or Medium Confidence [mixture exposure]; Note: Authors hypothesized that decreases in erythrocyte and hematocrit counts might indicate FA toxicity on bone marrow hematopoiesis
(Jakab et al., 2010) | Human female pathologists or controls (n = 37) | 0.9 mg/m^3^ (8 hr-TWA exposure); mean duration >17 years; slightly more (not significant) smokers and drinkers in exposed | Serum lymphocyte parameters: CD71 in fresh cells; apoptosis/ proliferation in cells cultured with PHA | N/C in T cell activation marker, CD71; Exposure to FA alone increased apoptosis and 1 out of 3 measures of cell proliferation in PBLs; N/C % in S phase | High or Medium Confidence - CD71 [limited precision of exposure assessment - sampling 1–3 years from study]; Low Confidence -other measures [ex vivo; limited exposure assess]
(Bellisario et al., 2016) | Human nurses (Italian females, years employed NR) | 0.034 ± 0.038 mg/m^3^ using formalin (n = 64); 0.015 ± 0.005 mg/m^3^ not using formalin (n=30), but noting that they did receive some exposure; 8-hr workshift measures on 2 separate days | 15-F_2t_ Isoprostanes and malondialdehyde in urine, normalized to creatinine (also measured cotinine) | Smoking and air-formaldehyde exposure were independently (positively) associated with increased oxidative stress biomarkers by pairwise comparisons and regression (note: in nurses who used vacuum sealing techniques, which reduce formaldehyde exposure, also exhibited reduced biomarkers). | Low Confidence - indirect [accuracy of single measure questionable]; small exposure differential; formalin test article; Note: serum and urine isoprostanes are correlated (Rodrigo et al., 2007); thus, this finding is indirect for serum ROS
(Erdei et al., 2003) | Human (sex NR) symptomatic students (9–11 yo w/ respiratory issues) (n=176) | 0.006–0.057 mg/m^3^ (average= 0.018); duration unknown [co-exposure: NO_2_, benzene, toluene, xylene, and dust mite allergen] | Serum Cell Counts | Increased serum monocyte counts by linear regression; N/C in RBCs, WBCs, platelets, lymphocytes, neutrophils (mostly), or eosinophils (all data NR) | Low Confidence [comparisons to “normal” range rather than to control group; co-exposure; limited reporting]; Note: symptomatic only
(Kuo et al., 1997) | Human dialysis nurses (n = 51) or ward nurses controls (n = 71) | Personal sampling ranged from 0.018–0.11 mg/m^3^; area sampling was as high as 3.44 mg/m^3^ (duration average= 3 year; ≈1/3 employed <1 year and ≈40% > 3 year); control area levels N/R | Blood cell counts | WBC decreased in 2^nd^ blood test (1 year after the first test at study onset- N/C): associated with FA concentration and symptoms, but not work duration (correlated, but N/S) N/C RBC, Ht, MCV, MCH, MCHC, Plt, neutrophil, lymphocyte, monocyte, eosinophil, or basophils | Low Confidence [not clear that controls are appropriately unexposed nor what co-exposures exist]; (Note: 2^nd^ blood test, presumably, would involve an extra 1 year of exposure duration)
(Thrasher et al., 1987) | Human symptomatic exposed subjects, controls (n = 8/ group) | Exposed (mobile home measures): 0.086–0.68 mg/m^3^ (residency ≈6–7 year); nonexposed: not measured (authors assume: <0.037) | Serum cell counts Ex vivo T and B cell blastogenesis (PHA or PWM stimulation) | T cell number decreased; B cell counts were not significantly changed T cell blastogenesis with PHA (not PWM: p>0.05, authors call significant) impaired | Low Confidence [small sample; symptomatic vs. nonsymptomatic comparison; questionable reporting]
(Thrasher et al., 1990) | Human various exposed groups of patients, and asymptomatic controls | “controls”- chiropractic students (n = 28): assumed ≥ 0.53 mg/m^3^ for 28 wk (13 hr/wk); mobile home residents (n = 19): 0.062– 0.62 mg/m^3^ for 2–7 year; office workers (n = 21): assumed 0.012–0.95 mg/m^3^, duration N/R; occupational (n=8): levels/ duration N/R; removed from exposure for ≥ 1 year: 0.17–1.0 mg/m^3^ | Blood cell counts | Decreased WBCs in office workers; N/C in all T cells, T helper or T suppressor cells, or T cell H/S ratio; Ta1+ lymphocytes (antigenic stimulation) elevated in all exposed patient groups B cells increased in office workers and removed patients; IL2R+ lymphocytes increased in mobile home residents and removed patients | Low Confidence [limited exposure contrast- authors suggest the only real difference between asymptomatic control students and patients is one of duration of exposure; patients to nonpatients comparisons questionable]
(Ying et al., 1999) | Human anatomy students (n = 23) | 0.508 ± 0.3 mg/m^3^ for 8 wks (3 hr/d, 3 d/ wk); in dormitories: 0.012 ± 0.003 | Serum lymphocyte subsets; Ex vivo lymphocyte proliferation (culture lymphoblast counts) | After exposure compared to before exposure: Increased % B cells (CD19), decreased Total T cells (CD3), T helper (CD4) and T cyto. (CD8) cells; N/C in ex vivo lymphocyte proliferation rate | Low Confidence [limited periodicity; some experiments ex vivo]; Note: internally controlled
(Madison et al., 1991) | Human residents, spill-exposed (n = 41) or unexposed controls (n=29) | Formaldehyde (PFA): >2.46 mg/m^3^ for first 48 hr, then average dropped to 0.028 mg/m^3^, but urea and methylamines not measured or corrected for | Serum cell counts | N/C in WBC, lymphocyte, CD8, CD8/CD4 ratio, CD19, or CD25 cells Decreased % CD5+ and % CD4+, although total counts of these were unchanged Increased CD26+ counts and % | Not Informative [mixture exposure; co-exposures not corrected for; FA in controls unmeasured]
(Vargová et al., 1992) | Human Woodworkers (Czechoslovakia) | Formaldehyde 0.55–10.36 mg/m^3^ and other, unquantified exposures | Serum IgG, IgA, IgM, IgE; Complement and other factors; Lymphocyte proliferation | Increased lymphocyte proliferation to concanavalin A and decreased proliferation to phytohaemaglutinin “no significant differences in natural cellular and specific humoral immunity” | Not Informative [mixture exposure; co-exposures not corrected for; FA in controls unmeasured; no description of recruitment or how referents were matched- reporting limited]
(Zhang et al., 2010) | Human formaldehyde melamine workers | 51 Controls: <0.037 mg/m^3^; 43 Exposed: 1.57 (0.77–3.09) mg/m^3^; Duration at least 3 mos (41/43 exposed >1 year) | In vitro proliferation of a volunteer’s cells | Decreased colony formation in cultured progenitors with in vitro FA treatment | Not Informative [formalin treatment- assumed; single donor, in vitro; nongaseous exposure, levels relevance]
Controlled-Exposure Studies in Humans or Primary Human Cells
(Dietrich et al., 1996) | In vitro human leukocytes (single donor): not further described | Formalin (assumed; test article N/R) gas at 0.62 mg/m^3^ for 1 hr | Heat shock protein 70 levels (Westerns) | FA, but not heat (42°C) stress, caused a significant increase in HSP70 levels | Not Informative [formalin; in vitro; short duration; exposure level relevance unknown; sample size NR; poor reporting]
Controlled-Exposure Studies in Animals, Animal Cells, or Immortalized Human Cells
(Sorg et al., 2001a) | Male SD rats (n = 6–9/ group) | PFA (inferred from citation) 0, 0.86, or 2.95 mg/m^3^ for 20–60 min, 2 or 4 wk | Serum corticosterone | N/C with acute exposure Increased CORT at 2.95 mg/m^3^ at 2 or 4 wk | High or Medium Confidence Note: unclear utility of endpoint for respiratory effects interpretation
(Rager et al., 2014) | Male fischer rats (n = 3) | PFA 0 or 2.46 mg/m^3^ for 7 d, 28 d or 28 d with 7 d recovery (6 hr/d) | miRNA microarray of blood WBCs | WBCs miRNAs were changed after 7 d or 28 d or 28 d with recovery (31 or 8 or 3 transcripts); associated primarily with inflammation and immunity | High or Medium Confidence [small sample size]; Note: unclear/indirect interpretation of endpoints
(Morgan et al., 2017) | Male B6.Trp53^tm1Brd^ and C3B6.129F1- Trp53^tm1Brd^ mice (heterozygote P53 allele); n = 25/group | PFA 0, 9.23, or 18.45 mg/m^3^ for 8 wks (6 hr/d, 5 d/wk) with measures at approximately 1 year | Whole blood counts | N/C in hematological parameters, including RBC, WBC, neutropils, monocytes, eosinophils, platelets, lymphocytes, reticulocytes, hemoglobin, hematocrit, MCV, MCH, or MCHC | High or Medium Confidence
(Dean et al., 1984) | Female B6C3F1 mice (n 1 0/ group) | PFA 0 or 18.5 mg/m^3^ for 3 wk (6 hr/d, 5 d/wk) | Serum cell counts | N/C peripheral blood cell counts, including WBC differentials, except: Decreased number of monocytes (from 43 to 4) | Low Confidence [excessively high levels: 60-70% RB inferred at these levels]; Note: monocyte decrease speculated as peripheral response to nasal inflammation and healing
(Aydin et al., 2014) | Male SD rats (n = 6/ group) | Test article unclear, but appears to be formalin in this experiment at 0, 6.48 (low), 12.3 (moderate), or 18.7 mg/m^3^ for 4 wk (8 hr/d, 5 d/wk) | Serum total antioxidant and total oxidant levels (TAS and TOS; kit uses vitamin E and H_2_O_2_ as reference, respectively Serum oxidative stress index (OSI: TOS/TAS) Serum irisin (hormone may regulate obesity) | Increased TOS, and decreased TAS and irisin, at ≥ 12.3 mg/m^3^ formaldehyde Increased OSI at ≥6.48 mg/m^3^; Note: serum biochemical parameters (e.g., cholesterol) are not included here, but were unchanged. Carnosine supplementation reduced changes. | Low Confidence [formalin; high levels]
(Zhang et al., 2013) | Male Balb/c mice (n = 9) | Formalin 0, 0.5, or 3 mg/m^3^ for 2 wk (8 hr/d, 5 d/wk) | Serum cell counts | D/D Decreased serum WBC, RBC, and lymphocytes, and increased platelets, at ≥0.5 FA; decreased intermediate cells at 0.5 FA; N/C in neutrophils | Low Confidence [formalin]
Ye et al., 2013) | Male Balb/c mice (n ≥9/ group/ endpoint) | Formalin 0, 0.5, 1, or 3 mg/m^3^ for 7 d (8 hr/d) | ROS (dichlorohydroflourescein and MDA) blood mononuclear cells (PBMC) | Dose-dependent decrease in GSH levels in PBMC at ≥1; Dose-dependent increase in DCFH and MDA in PBMC at 3; Co-administered GSH attenuated effects | Low Confidence [formalin]
(Im et al., 2006) | Male SD rats (n = 10) | Formalin (assumed; test article not specified) 0, 6.15, 12.3 mg/m^3^ for 2 wks (6 hr/d; 5 d/wk) | Plasma ROS, cytokines, and proteomic analysis | Increased MDA & protein carbonyls at 12.3 mg/m^3^ (note: similar increases in liver); D/D Increased IL-4 and decreased IFNγ Other protein changes (e.g, increased GSTs and ApoE; decreased heme oxygenase, fibrinogen, ApoA1, SNAP-25 | Low Confidence [formalin; high levels]
Matsuoka et al., 2010) | Male ICR mice (n ≥ 7) | Formalin at 0.12 mg/m^3^ for up to 24 hr; also, a single experiment at 3.69 mg/m^3^ for 24 hr | Plasma ROS (8OHdG) and NO (nitrates/nitrites); NO response to LPS injection: 3.69 mg/m^3^ | Increased plasma ROS at 0.12 mg/m^3^ for ≥8 hr and NO at 24 hr; Increased plasma SOD activity at 3.69 mg/m^3^; N/C in plasma IL-6 at 0.12 mg/m^3^ Decreased NO_3_ with LPS stimulation | Low Confidence [formalin; short duration]; NOTE: ACUTE
(Sandikci et al., 2007b) | SD rats (n = 6/group) at GD1 [I], PND1 [II], PND28 [III] or adults [IV] | Formalin (assumed: test article NR): 0 or 7.38 mg/m^3^ for 6 wk (8 hr/d, 7 d/wk) | Blood T lymphocyte counts | Increased blood T lymphocytes (ANAE+ as marker) in all groups by FA | Low Confidence [formalin; high exposure levels; use of ANAE as T lymphocyte marker under all conditions has been debated]
(Katsnelson et al., 2013) | Rat “white” females (n = 12– 15) | Formalin (assumed; test article NR) 12.8 ± 0.69 mg/m^3^ for 10 wk (4 hr/d, 5 d/wk) | Blood cell counts and immune markers (other markers N/C or not inflammation) | Increased % lymphocytes and albumin; Decreased % segmented neutrophils, MDA, GSH, and lymphocyte SDH activity; some decreased serum amino acids | Low Confidence [formalin; excessively high levels; short periodicity]
Yu et al., 2014b | Male ICR mice (n = 6) | Formalin 20, 40, 80 mg/m^3^ for 15 d (2 hr/d) | Blood cell counts | Decreased blood WBCs and platelets at ≥ 40 mg/m^3^ | Low Confidence [formalin; excessively high levels; short periodicity]
Brondeau et al., 1990) | Male SD rats (n = 10) | Formalin (assumed; test article NR) 35.7–75 mg/m^3^ for 4 hr, with or without adrenalectomy | Serum cell counts | Decreased WBCs at ≥ 52.9 mg/m^3^, not at 35.7 mg/m^3^; N/C in RBCs Adrenalectomized rats did not show decreased WBCs at 60.3 mg/m^3^ | Low Confidence [formalin; excessively high levels; short periodicity]; NOTE: ACUTE
(Zhao et al., 2020) | Male Balb/c mice (n = 3, pooled into single sample for nose and lung samples); 2 experiments by different researchers | Formalin 0, 3 mg/m^3^ for 2 wks (8 hr/d, 5 d/wk) | Burst-forming unit-erythroid (BFU-E), and colony-forming unitgranulocyte macrophage (CFU-GM) colonies in nose, lung, spleen, and bone marrow | Bone marrow results: Decreased formation of CFU-GM and BFU-E in both experiment I and II | Low Confidence [formalin; small sample size]; Not Informative: ex vivo results
(Wei et al., 2014) | Male C57BL/6 mice (n = 6) | Methanol-free formalin at 0, 0.5, or 2 mg/kg/d for 1 wk or 1 mo (5 d/wk) | Serum cytokines for Th1, Th2, and Th17 | Increased Th1-related cytokines (IFN-γ, TNF, and IL-2), TH2-related cytokines (IL4, IL-6, and IL-10), and Th17-related cytokine (IL-17A) at 2 mg/kg/d for 1 or 4 wks; specific statistically significant increases only noted for 1 wk IL-2 and IL4 levels (note: magnitude of change was equal or greater at 1 mo and for all tested cytokines in all comparisons; in general, small decreased levels noted at 0.5 mg/kg) | Not Informative [levels of unknown relevance; i.p. injection]; Note: Kruskal-wallis test
(Ibrahim et al., 2016) | Pregnant Wistar rats (n = 5 dams; 10 pups/ group for experiments; note: individual pup data for n = 10 pups did not appear to account for litters) | Formalin 0.92 mg/m^3^ from GDs 1–21: 1 hr/d, 5 d/wk | Blood cell counts and Myeloperoxidase activity | Increases in total cells and granulocytes (lymphocytes and monocytes were unchanged) by LPS were reduced in offspring exposed to formaldehyde, as were increases in myeloperoxidase activity | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects]; Note: effects rescued by vitamin C
(Ibrahim et al., 2016) | Pregnant Wistar rats (n = 5 dams; 10 pups/ group for experiments; note: individual pup data for n = 10 pups did not appear to account for litters) | Randomly assigned pups all received 5 mg/kg lipopolysacharride (LPS) injections at PND 30 | | Increases in total cells and granulocytes (lymphocytes and monocytes were unchanged) by LPS were reduced in offspring exposed to formaldehyde, as were increases in myeloperoxidase activity | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects]; Note: effects rescued by vitamin C
(Maiellaro et al., 2014) | Pregnant Wistar rats (n = 5) | Formalin 0.92 mg/m^3^ from GDs 1–21: 1 hr/d, 5 d/wk | Blood cell counts | N/C in parental blood total cells, monocytes, lymphocytes, or granulocytes Decreased birth weight in offspring 24 hr after OVA challenge, offspring have: decreased blood total cells, mononuclear cells, neutrophils, and eosinophils | Not Informative [formalin, short periodicity, offspring comparisons do not include FA alone; small sample size]
(Maiellaro et al., 2014) | Pregnant Wistar rats (n = 5) | Sensitization: s.c. 10 µg OVA with sc boost after 7d Challenge: 7 d later, 1% OVA aerosol 15 min/d, 3 d | | | Not Informative [formalin, short periodicity, offspring comparisons do not include FA alone; small sample size]
(Kum et al., 2007b) | Female SD rats (n = 6) | Formalin (assumed: test article NR): 0 or 7.38 mg/m^3^ for 6 wks (8 hr/d, 7 d/wk) | Serum biochemistry (proteins and factors) | Increased serum urea, but N/C in total protein, albumin, or creatinine Note: experiments with FA + xylene not considered | Not Informative [formalin; high levels; tests not considered relevant to inflammation or respiratory effects]
(Ciftci et al., 2015) | Male Wistar albino rats (n = 10) | Formalin i.p. injection at 9 mg/kg-d every other day for 2 wks | Serum markers for ROS, antioxidants, as well as beta amyloid and tumor protein 53 levels | Increased MDA (ROS marker) Decreased total antioxidants, TP53, and A-beta1-40 (not 1–-42) | Not Informative [formalin; high levels of unknown relevance; i.p. injection]
(Murta et al., 2016) | Male Fischer rats (n = 7) | Formalin (assumed) 1%, 5%, or 10% for 5 d (3 × 20 min/d) | Blood cell counts, chemokine levels, and ROS indicators | FA increased total leukocyte, lymphocytes at 5%, and decreased platelets at 10%; N/C in other cell types; 1% caused increased catalase and other ROS indicators were observed; increased CCL2 at 10%, CCL3 at 1–5%, and CCL5 at 1% | Not Informative [formalin; unquantified high levels; static exposure chamber; short periodicity]
(da Silva et al., 2015) | Male Wistar rats (n = 6/ group) | Formalin 1% for 3 d (90 min/d); rats exposed in static chambers 5 rats/time | Blood cell counts | FA increased total cells, monocytes, lymphocytes, and neutrophils Note: while reduced effects were reported as reduced with laser therapy, laser therapy-only controls were not used | Not Informative [formalin; unquantified high levels; static exposure chamber and group exposure; short duration and periodicity]
(Lino dos Santos Franco et al., 2006) | Male Wistar rats (n = 5–6) | Formalin 1% or methanol vehicle for 4 d (30, 60, or 90 min/d) | Serum cell counts | Increased serum leukocytes and mononuclear cells, but not neutrophils | Not Informative [formalin (MeOH controls); unquantified high levels; short periodicity; small sample size; presented comparisons to naïve rats rather than MeOH controls]
(Lino-Dos-Santos-Franco et al., 2011a) | Female Wistar rats (n = 5) | Formalin 1% or naïve for 3 d (90 min/d), with or without ovariectomy | Serum cell counts and factors | Increased total serum leukocytes Increased serum corticosterone | Not Informative [formalin; impact of sham surgery NR; short periodicity and duration; unquantified high level; FA alone untested; naïve not chamber exposed; small sample size]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n = 5) | Formalin 0, 1% for 3 d (90 min/d) | Serum cell counts | Increased Total serum leukocytes and mononuclear cells, not neutrophils; FA inhibited OVA-induced increases | Not Informative [formalin; unquantified high level; small sample size; short duration and periodicity]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n = 5) | Sensitization: immediately post-FA, i.p. 10 µg OVA; boost 1 wk later with s.c. injection Challenge: 1 wk later with aerosolized OVA | | Increased Total serum leukocytes and mononuclear cells, not neutrophils; FA inhibited OVA-induced increases | Not Informative [formalin; unquantified high level; small sample size; short duration and periodicity]

##### Effects on other immune system-related tissues (e.g., bone marrow, spleen, thymus, lymph)

Table B-47 Effects on other immune system-related tissues (e.g., bone marrow, spleen, thymus, lymph nodes, etc.)

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
[underlined: Controlled-Exposure Studies in Animals, Animal Cells, or Immortalized Human Cells]
(Fujimaki et al.. 2004b) | Female C3H mice (n=5-6 per group) | PFA0, 0.098,0.49, or 2.46 mg/m^3^; 12 wks | Splenic Cell counts Ex vivo splenic cells | No significant change in counts of splenic CD3 T cells, CD19 B cells, or CD4/CD8 ratio D/D Increased IFNy with LPS stimulation of cells at 2.46 mg/m^3^; D/D Increased MCP-1 at ≥ 0.49 mg/m^3^ in cells of OVA-stimulated mice; N/C in IFNy, MIP-1α or IL-5; Body weight decreased at ≥0.49 mg/m^3^ | High or Medium Confidence [small sample size]: cell counts; Low Confidence [small sample size; ex vivo]: cytokine measures
(Fujimaki et al.. 2004b) | Female C3H mice (n=5-6 per group) | Sensitization: i.p. 10 μg OVA prior to FA exposure; aerosol OVA boost for 6 min on wks 3, 6, 9, and 11 | | | High or Medium Confidence [small sample size]: cell counts; Low Confidence [small sample size; ex vivo]: cytokine measures
(Rager et al., 2014) | Male Fischer rats (n=3) | PFA 0 or 2.46 mg/m^3^ for 7 d, 28 d or 28 d with 7 d recovery (6 hr/d) | miRNA microarray of femur BM cells | N/C in BM miRNAs at any time | High or Medium Confidence [small sample size]; NOTE: indirect interpretation of endpoints
(Ma et al., 2020) | Male BALB/c mice (n=8) | Methanol-free formalin 0 or 2 mg/m^3^ for 8 wks (8 hr/d, 7 d/w) | T cells in the spleen (mature) and thymus (immature) | Spleen: Decreased CD8+ and increased CD4/CD8 ratio; N/C in organ weight and CD4+ cells; Thymus: Increased CD4/CD8 ratio; Decreased organ weight and CD8SP cells; N/C in CD4SP cells | High or Medium Confidence: counts; NOTE: experiments in directly treated cells considered Not informative for these endpoints (not extracted)
(Park et al. 2020) | Female BALB/c mice (n=10) | Fresh formaldehyde solution (methanol-free) 0, 1.38, 5.36 mg/m^3^ for 2 wks (4 hr/d, 5 d/wk) | Splenic cytokines, T cell populations and Th1/Th2 balance, differentiation markers | Spleen: N/C in CD4+ T helper cells, D/D increased T reg cells (CD4+CD25+Foxp3+) subset of CD4+ cells; Increased calcinurin and NFAT1 (regulatory and inhibitory functions), N/C in NFAT2; Spleen (ex vivo production): D/D decreased IL-4, IL-5, IL-13, IFN-g, IL-17A, and IL-22 with similar changes in mRNA for same; [also, N/C in relative spleen wt. and increased rel. lung wt. at 5.36 mg/m^3^] | High or Medium Confidence [small sample size]
(Dean et al., 1984) | Female B6C3F1 mice (n=6-10/group/ endpoint, except n=5 for splenocyte assays) | PFA 18.5 mg/m^3^ for 21 d (6 hr/d, 5 d/wk) | Lymphoid organ weights/cellularity Host immunity response | N/C in thymus or spleen weight; N/C in BM cells/femur or spleen cell counts; N/C in CFU in spleen or BM; N/C in splenic lymphocyte proliferation or splenic B cell IgM production; N/C in cell-mediated immunity (response of spleen lymphocytes to mitogens, splenocyte cell surface markers, NK cell cytotoxicity) or humoral immunity (number of IgM Ab-producing B cells for 3 separate antigens); Decreased host susceptibility to bacteria challenge, but not tumor challenge; N/C in hypersensitivity or NK cytotoxicity | Low Confidence [excessively high levels small sample size; some experiments ex vivo]; NOTE: 60-70% RB inferred
(Liu et al., 2017) | Male ICR mice (n= 10/group) | Unspecified test article 0, 1, 10mg/m^3^ for 20 wk (2 hr/d) | Bone marrow (BM) polychromatic erythrocytes (PCE)/normochromatic erythrocyte (NCE) ratio | Dose-dependent decrease in BM PCE/NCE ratio (markers of immature/mature RBCs), significant at ≥1 mg/m^3^ | Low Confidence [presumed formalin]
(Ye et al., 2013) | Male Balb/c mice (n≥9/group/ endpoint) | Formalin 0, 0.5, 1, or 3 mg/m^3^ for 7 d (8 hr/d) | ROS (dichlorohydro-flourescein and MDA) and GSH in BM and Spleen | Dose-dependent decrease in GSH levels in BM and spleen at ≥1; Dose-dependent increase in DCFH and MDA in BM and spleen at ≥1; Co-administered GSH attenuated effects on GSH, DCFH and MDA in all tissues | Low Confidence [formalin]
(Zhang et al., 2013) | Male Balb/c mice (n=9) | Formalin 0, 0.5, or 3 mg/m^3^ for 2 wk (8 hr/d, 5 d/wk) | BM ROS and cytokines/factors | BM increased megakaryocytes at ≥0.5 FA BM ROS (DCFH-DA) D/D increased at ≥0.5 FA; GSH decreased, and caspase-3 increased, at 3 FA; BM NFkB, TNFα, and IL-1β increased at 3 FA | Low Confidence [formalin]
(Zhao et al., 2020) | Male Balb/c mice (n=3, pooled into single sample for nose and lung samples); 2 experiments by different researchers | Formalin 0, 3 mg/m^3^ for 2 wks (8 hr/d, 5 d/wk) | Burst-forming unit-erythroid (BFU-E), and colony-forming unit-granulocyte macrophage (CFU-GM) colonies in nose, lung, spleen, and bone marrow | Spleen results:; Decreased formation of CFU-GM in both experiment I and II; Decreased formation of BFU-E in experiment II; N/C in experiment I | Low Confidence [formalin; small sample size]; Not Informative: ex vivo results
(Gu et al., 2008) | Female Balb/c and C3H/He mice (n=10 for in vivo; n=3 ex vivo experiments) | Formalin (assumed; test article NR) 0.098 mg/m^3^ for 5 wk (in vivo); 0.12, or 0.98 mg/m^3^ for 5 wk (ex vivo); both 24 hr/d, 5 d/wk | Splenic cell phenotypes Ex vivo cytotoxicity | N/C in T cell or B cell subtypes at 0.08 Increased NK1 cells (NK1.1 expression) at 0.098 mg/m^3^; Increased ex vivo NK1 cell cytotoxicity at ≥0.12 mg/m^3^ | Low Confidence [formalin]; Not Informative [small sample size; ex vivo; unclear reporting: ex vivo cytotoxicity
(Dallas et al., 1987) | Male SD rats (n=2/time point; unclear reporting) | PFA0, 0.62, 3.69, or 18.5 mg/m^3^ for 1 wk to 24 wk (6 h/d, 5 d/wk) | Flow cytometry DNA/RNA analysis of BM cell proliferation/health | N/C in RNA or DNA measures (e.g., % S phase) in BM cells | Low Confidence [small sample size; unclear reporting]; NOTE: indirect utility for evaluating respiratory effects or inflammation
(Kim et al., 2013b) | Female NC/Nga (atopic-prone) mice (n=5–6/group) | Formalin (assumed; test article NR) 0, 0.25, 1.23 mg/m^3^ for 4 wk (6 hr/d, 5 d/wk) | Cytokine mRNA for spleen | Spleen mRNA: FA D/D increase IL-13 only With HDM, FA exacerbated IL-4 (0.2), IL-5 (1.23 mg/m^3^), IL-13 and IL-17A (≥0.25 mg/m^3^), but caused D/D decreased IFNy (≥0.25 mg/m^3^) | Low Confidence [small sample size; unclear reporting]; NOTE: indirect utility for evaluating respiratory effects or inflammation
(Kim et al., 2013b) | Female NC/Nga (atopic-prone) mice (n=5–6/group) | Sensitization: topical house dust mite (HDM; ear) stimulation (25 mg Df ointment) 1x/wk for 4 wk | | Spleen mRNA: FA D/D increase IL-13 only With HDM, FA exacerbated IL-4 (0.2), IL-5 (1.23 mg/m^3^), IL-13 and IL-17A (≥0.25 mg/m^3^), but caused D/D decreased IFNy (≥0.25 mg/m^3^) | Low Confidence [small sample size; unclear reporting]; NOTE: indirect utility for evaluating respiratory effects or inflammation
(Kim et al., 2013a) | Female C57BL/6 mice (n=5 “experiments”; number of mice/group unclear) | Formalin (assumed; test article NR) 0, 6.15, or 12.3 mg/m^3^ 2–3 wk (6 hr/d, 5 d/wk) | Spleen and bone marrow cell counts Ex vivo cellular functional assays | N/C in absolute cell number or T cell or B cells subtypes in spleen or BM; No significant changes in %CD8 or % B cells in spleen; Decreased NK1 cells in spleen, including reduced function, which was inhibited at 12.3 mg/m^3^: duration-dependent | Low Confidence [formalin; unclear, low sample size; high levels]; Not Informative: ex vivo function
(Yu et al., 2014b) | Male ICR mice (n=6) | Formalin 20, 40, 80 mg/m^3^ for 15 d (2 hr/d) | BM histology, cell counts and ROS | Decreased BM cells observed by pathology and GSH-Px activity at ≥40 FA Increased MPO activity and protein and decreased Prx2 protein at ≥20 FA Decreased BM cells (karyocytes) and CFUs and MMP levels at 80 mg/m^3^; D/D increased BM oxidative stress (MDA increased and SOD decreased) ≥20 FA Increased BM apoptosis markers ≥40 FA | Low Confidence [formalin; excessively high levels; short periodicity]
(Yu et al., 2015a) | Male mice (strain NR; n=6/group) | Formalin 0, 20, 40, 80 mg/m^3^ for 15 d (2 hr/d) | BM H_2_O_2_ production, caspase and antioxidant enzyme levels/ activity, and apoptosis | Increased ex vivo caspase-3 activity, peroxiredoxin levels and H_2_O_2_ production at ≥20 mg/m^3^; Increased apoptosis at ≥40 mg/m^3^ | Low Confidence [formalin-excessively high levels; short periodicity]
(De Jong et al., 2009) | Male Balb/c mice (n=6) | Formalin 3.6 mg/m^3^ nose-only (up to 360 min/d for 3 d) | Ex vivo cytokine production from isolated lymph nodes | No cell proliferation in LNs N/C in IL-4, IL-10, or IFNy production from isolated cells by FA alone, but FA with sensitization results in increased IL-4 and IL-10 (and slight increase in IL-12), but N/C in IFNg | Low Confidence [formalin; short duration and periodicity; ex vivo]
(Zhang et al., 2014a) | Balb/c mice (n=3/sex/group) | Formalin 0,4, 8 mg/m^3^ for 7 d (6 hr/d) | Spleen and thymus weights Ex vivo spleen cell lymphocyte proliferation and ROS Urine metabolomics | Decreased relative spleen and thymus weights (only statistically significant for thymus at 8 mg/m^3^); Decreased ex vivo lymphocyte proliferation and SOD activity at ≥4 mg/m^3^ and increased ex vivo ROS at 8 mg/m^3^ | Low Confidence [formalin; ex vivo; no chamber control exposure; lowest tested exposure of 4 mg/m^3^]; Note: some ex vivo assays after in vivo exposure; n=6 (pooled sexes assumed- not explicit in reporting)
(Fujii et al., 2005) | Female Balb/c mice (n=6–10) | Formalin (assumed; test article NR) 0, 0.25 mg/m^3^; exposed during elicitation (reporting unclear) or sensitization (4 wk) or w/chronic hypersensitivity | Ex vivo lymph node cells all w/epicutaneous trinitrochlorobenzene TNCB | During elicitation: FA increased CD4+ T cells (IL-4+: Th2, not IFNy+: Thl), not CD8+, in draining lymph node (LN); During sensitization (and in CH model): FA increased LN CD8+ T cells (N/C CD4+; CD4+CD25+/CD4+ decrease) | Not Informative [formalin; ex vivo; reporting for some experiments unclear; No FA-only controls; short duration]
(da Silva et al., 2015) | Male Wistar rats (n=6/ group) | Formalin 1% for 3d (90 min/d); rats exposed in static chambers 5 rats/time | Bone marrow cell counts | FA caused N/C in total bone marrow cells Note: while reduced effects were reported as reduced with laser therapy, laser therapy-only controls were not used | Not Informative [formalin; unqualified high levels; static exposure chamber and group exposure; short duration and periodicity]
(Ibrahim et al., 2016) | Pregnant Wistar rats (n=5 dams; 10 pups/group for experiments; design did not appear to account for potential litter effects) | Formalin 0.92 mg/m^3^ from GDs 1-21: 1 hr/d, 5 d/wk | Total cells in femur lavage | Decreases in total cells by LPS were further reduced in offspring exposed to formaldehyde | Not Informative [formalin; short periodicity; offspring comparisons do not include FA without LPS; small sample size; did not appear to account for litter effects] Note: effects rescued by vitamin C; effects on dam uterine tissue not included in these tables
(Ibrahim et al., 2016) | Pregnant Wistar rats (n=5 dams; 10 pups/group for experiments; design did not appear to account for potential litter effects) | Randomly assigned pups all received 5mg/kg lipopolysacharride (LPS) injections at PND 30 | | Decreases in total cells by LPS were further reduced in offspring exposed to formaldehyde
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n=5) | Formalin 0, 1% for 3 d (90 min/d) | BM cell counts | N/C in total BM cells; FA inhibited OVA-induced increases) | Not Informative [formalin; unqualified high levels; small sample size; short duration and periodicity]
(Lino dos Santos Franco et al., 2009) | Male Wistar rats (n=5) | Sensitization: immediately post-FA, i.p. 10 μg OVA; boost 1 wk later with s.c. injection Challenge: 1 wk later with aerosolized OVA | | N/C in total BM cells; FA inhibited OVA-induced increases) | Not Informative [formalin; unqualified high levels; small sample size; short duration and periodicity]
(Lino-Dos-Santos-Franco et al., 2011a) | Female Wistar rats (n=5) | Formalin 1% or naive for 3 d (90 min/d), with or without ovariectomy | Bone marrow cell counts | Decreased total bone marrow cells | Not Informative [formalin; impact of sham surgery; unqualified high levels; FA alone untested; naive not chamber exposed; small sample size; short duration & periodicity]
(Lino dos Santos Franco et al., 2006) | Male Wistar (n=5–6) | Formalin 1% or methanol vehicle for 4 d (30, 60, or 90 min/d) | Splenic and bone marrow cell counts | Increased total splenic cells, but total bone marrow cells unchanged | Not Informative [formalin (MeOH controls); unqualified high levels; small sample size; short duration and periodicity; comparisons to naive rats rather than MeOH controls]
(Golalipour et al., 2008) | Wistar albino rats (n=7; sex N/R) | Mixture (dissection room vapor of undocumented composition) =1.85 mg/m^3^ for 18 wk: 2 hr/d for 2 d/wk, 4 d/wk, or 4 hr/d for 4d/wk | Spleen morphometry | Frequency-dependent increases in white pulp diameter and marginal zone diameter | Not Informative [mixture exposure; short periodicity; poor reporting; controls do not account for co-exposures; quantitative comparisons for results NR]

#### Evaluation of Mechanistic Evidence for Effects on Tissues Other than those of Interest to the Current Analysis

Table B-48 Effects on other tissues (data extracted for possible future consideration, but not included in this assessment)

Study | System | Exposure | Endpoint(s) | Results | Utility and notes
(Fuijmaki et al., 1992) | In vitro male SD Rat peritoneal mast cells (n = 3+ experiments) | PFAO, 1.23, 6.15, 12.3, 61.5 mg/m^3^ for 30 min; stimuli: substance P, A23187 (increases cellular Ca2+ and NO production), and ant-rat IgE (in sensitized cells) | Peritoneal mast cell Histamine release | Enhanced histamine release stimulated by A23187 and anti-lgE at ≥ 6.15 mg/m^3^; enhanced release by substance P at 61.5 mg/m3 (note: release was inhibited by PLA2 inhibition, but not by antioxidant or dexamethasone) | Excluded (not tissues of interest) [In vitro; questionable relevance of peritoneal cells and exposure levels]
(Fujii et al., 2005) | Female Balb/c mice (n = 6-10) | Formalin (assumed; test article NR) 0, 0.25 mg/m^3^; exposed during elicitation (reporting unclear) or sensitization (4 wk) or w/ chronic hypersensitivity (CH)—all w/ epicutaneous trinitrochlorobenzene | Ear swelling, skin histopathology | During elicitation: FA suppressed contact hypersensitivity (i.e., decreased ear swelling and edema); During sensitization (and in CH model): FA increased swelling, edema, and mast cell infiltration | Excluded (not tissues of interest) [Formalin; reporting for some experiments unclear; No FA-only controls; endpoint relevance unclear]
(Dean et al., 1984) | Female B6C3F1 mice (n=5-10/group/endpoint) | PFA18.5mg/m^3^ for 21 d (6 hr/d, 5 d/wk) | Peritoneal macrophage function | N/C in peritoneal macrophage function, except: FA-increased H2O2 production by macrophages isolated after injection with MVE-2 and stimulation with PMA | Excluded (not tissues of interest) [Excessively high exposure levels; small sample size]
(Adams et al., 1987) | Female B6C3F1 mice (n=10) | PFA18.5mg/m^3^ for 3 wk (6 hr/d, 5 d /wk) | Peritoneal macrophage counts and function (some in ex vivo cultures) | N/C in macrophage number or phagocytosis of antibody-covered erythrocytes; FA decreased leucine aminopeptidase expression FA increased release of ROS in response to external challenge (MVE-2 priming and PMA stimulus); N/C w/o challenge | Excluded (not tissues of interest) [Excessively high levels]
(Kim et al., 2013b) | Female NC/Nga (atopic-prone) mice | Formalin (assumed; test article NR) 0, 0.25, 1.23 mg/m^3^ for 4 wk (6 hr/d, 5 d/wk) | Atopic dermatitis/Ear skin Inflammation Cytokine mRNA for ear skin | FA increased AD-like clinical skin inflammation by HDM, but not FA alone Mast cell infiltration in dermis by FA alone, exacerbates HDM eosinophil & mast cell; Skin mRNA: 0.25 mg/m^3^ increased IL-13JL-17A, COX-2; with HDM, FA exacerbated these and IFNy, IL-4, and TSLP; N/C IL-5 | Excluded (not tissues of interest) [Formalin; small sample size]; Note: unclear utility for evaluating respiratory effects or inflammation; multiple supplementary files; eosinophil data not reported
(Kim et al., 2013b) | Female NC/Nga (atopic-prone) mice | Sensitization: topical house dust mite (HDM; ear) stimulation (25 mg Df ointment) 1x/wk for 4 wk | | | Excluded (not tissues of interest) [Formalin; small sample size]; Note: unclear utility for evaluating respiratory effects or inflammation; multiple supplementary files; eosinophil data not reported
(Maiellaro et al., 2014) | Pregnant Wistar rats (n=5) | Formalin 0.92 mg/m^3^ from GD1-GD21: 1hr/d, 5 d/wk | Uterine factors | Decreased uterine IL-10, SOD2, and cNOS, and increased COX-1, at birth (N/C in IL-6, IL-4, IFNy, COX-2, iNOS, SOD1, or catalase) Decreased birth weight in offspring | Excluded (not tissues of interest) [Formalin, short duration, offspring comparisons do not include FA alone]
(Maiellaro et al., 2014) | Pregnant Wistar rats (n=5) | Sensitization: s.c. 10ug OVA with sc boost after 7 d Challenge: 7 d later, 1% OVA aerosol 15 min/d, 3 d | | Decreased uterine IL-10, SOD2, and cNOS, and increased COX-1, at birth (N/C in IL-6, IL-4, IFNy, COX-2, iNOS, SOD1, or catalase) Decreased birth weight in offspring | Excluded (not tissues of interest) [Formalin, short duration, offspring comparisons do not include FA alone]
(Aydin et al., 2014) | Male SD rats (n=6/group) | Test article unclear, but appears to be formalin in this experiment at 0, 6.48 (low), 12.3 (moderate), or 18.7 mg/m^3^ for 4 wk (8 hr/d, 5 d/wk) | Liver tissue total antioxidant and total oxidant levels (TAS and TOS; kit uses vitamin E and H2O2 as reference, respectively Liver tissue apoptotic index and oxidative stress index (OSI: TOS/TAS) | Increased TOS and decreased TAS, at ≥ 12.3 mg/m^3^ formaldehyde; Decreased irisin and increased OSI at ≥6.48 mg/m^3^; Note: Carnosine supplementation reduced changes. | Excluded (not tissues of interest) [Formalin; high levels]
(Bakar et al., 2015) | Male Wistar albino rats (n=7) | i.p. Formalin every other day at 1 mg/kg-d for 14 d | Kidney biochemistry, immunoreactivity for Bcl-2 and Bax, ROS and antioxidant markers, and electron microscopy | Increased Bcl-2 and Bax immunostaining, and increased ROS markers and altered antioxidant enzyme activities; kidney damage and inflammation noted | Excluded (not tissues of interest) [Formalin; high levels of unknown comparability to inhaled levels; i.p. injection]
(Matsuoka et al., 2010) | Male ICR mice (n≥7) | Formalin at 0.12 mg/m^3^ for up to 24 hr; also, a single experiment at 3.69 mg/m^3^ for 24 hr with LPS | Urine, liver, brain ROS (8OHdG) and NO metabolites (nitrates/nitrites) | Decreased ROS in urine and liver; N/C in brain; decreased NO in urine, liver and brain at 0.12 mg/m^3^ at 24 hr Increased urinary SOD activity:3.69 mg/m^3^ | Excluded (not tissues of interest) [Formalin; short duration]
(Kum et al., 2007a) | Female SD rats (n=6/group) at GDI [I], PND1 [II], PND28 [III] or adults [IV] | Formalin (assumed: test article NR):0 or 7.38 mg/m^3^ for 6 wk (8 hr/d, 7 d/wk) | Liver oxidative stress (i.e., SOT, CAT, GSH, MDA) | CAT activity and MDA levels increased [I] GSH decreased in [II] SOD activity decreased [III] N/C in adult [IV] oxidative stress markers Note: body and liver weight decreased in 1 and II; liver weight increased in III | Excluded (not tissues of interest) [Formalin, high levels; limited assays]
(Kum et al., 2007b) | Female SD rats (n=6/ group) | Formalin (assumed: test article NR):0 or 7.38 mg/m^3^ for 6 wk (8 hr/d, 7 d/wk); | Renal oxidative stress | N/C in renal SOD, CAT, GSH-Px, GSH, or MDA by FA alone | Excluded (not tissues of interest) [Formalin, high levels; limited assays]
(Ciftci et al., 2015) | Male Wistar albino rats (n=10) | Formalin i.p. injection at 9 mg/kg-d every other day for 2 wks | Brain and urine oxidative DNA damage Beta amyloid in brain | Increased A-betal-42 in brain Increased brain DNA 8-Ohdg damage; slightly increased (nonsignificant-assumed) DNA damage in urine | Excluded (not tissues of interest) [high levels of unkown relevance; i.p. injection; formalin]
(Ye et al., 2013) | Male Balb/c mice (n≥9/group/endpoint) | Formalin 0,0.5,1, or 3 mg/m^3^ for 7 d (8 hr/d) | ROS (dichlorohydro-flourescein and MDA) and GSH in Liver and Testes | D/D decrease in GSH levels in liver at ≥0.5 mg/m^3^; decreased in testes at 3 mg/m^3^ D/D increase in DCFH and MDA in liver at ≥0.5 mg/m^3^; in testes at ≥1 mg/m^3^; co-administered GSH attenuated effects on GSH, DCFH and MDA in all tissues | Excluded (not tissues of interest) [Formalin]
(Jiang et al., 2015) | In vitro PC12 (immortalized neuronal) cells (n=3 technical replicates) | Formalin (assumed; test article NR)—in vitro levels of unknown relevance | Viability, neurotrophic factor, and ROS markers | Decreased BDNF and viability Increased MDA and other ROS markers | Excluded (not tissues of interest); [Formalin, high levels of unknown relevance; in vitro; small sample size]
(Kim et al. 2013a) | Female C57BL/6 mice (n=5 “experiments”; number of mice/group unclear) | Formalin (assumed; test article NR) 0, 6.15, or 12.3 mg/m^3^ 2–3 wk (6 hr/d, 5 d/wk) | liver cell counts Ex vivo cellular functional assays | N/C in absolute cell number or T cell or B cells subtypes in liver | Excluded (not tissues of interest) [Formalin; unclear sample size]
(Güleç et al., 2006) | Wistar albino rats (n=10; sex NR) | PFA 0, 12.3 or 24.6 mg/m^3^ (8 hr/d, 5 d/wk) for 4 or 13 wk | Heart oxidative stress (i.e., SOD, CAT, TBARS, NO) | Increased SOD at ≥ 12.3 mg/m^3^ (4 or 13 wk); Decreased CAT at ≥ 12.3 mg/m^3^ at 4 wks, but not 13 wk; N/C in TBARS or NO | Excluded (not tissues of interest) [excessively high levels; limited assays]
(Xin et al., 2015) | HepG2 (liver) cells; n=3 technical replicates | Formalin; in vitro (unknown relevance) | Heat shock protein reporter assays | Increased promotion of HSPA1, correlated with oxidative stress and cellular damage | Excluded (not tissues of interest) [in vitro; high levels; formalin; small sample size]

### B.3.7 Nervous System Effects

The details of the study evaluation approach methods are provided in Section 2.3.7 of the Toxicological Review. Within Table B-49 (epidemiology studies of ALS and neurobehavior), Table B-50 (controlled exposure studies in humans), Table B-51 (animal studies), and Table B-52 (mechanistic studies of inhalation exposure) below documenting the results of the study evaluations for nervous system effects, studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating.

#### Observational Epidemiology Studies

Table B-49 Evaluation of observational epidemiology studies of formaldehyde—neurological effects

Reference, setting, and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Amyotrophic Lateral Sclerosis (ALS)
Bellavia et al. (2021), (Denmark) Population-based nested case-control | ALS cases, 1982-2009, from Seals et al. (2017) with data for several health factors and environmental risk factors previously linked with ALS. Controls, 100 per case matched on being alive on index date for case diagnosis, same birth year and sex. Excluded individuals with less than 5 years work experience. | Occupational histories obtained from Danish Pension Fund databases. Used NOCCA (Nordic Occupational Cancer Study)- Danish JEM for periods 1960–74, 1975–84, and 1985 and after. Formaldehyde exposure metric was ever/never exposed. Anticipate exposure misclassification and large variation in prevalence and intensity of exposure across individuals. In men, correlations between formaldehyde, diesel exhaust and solvents were 0.22 and 0.41, respectively (Phi coefficients) | Danish National Patient Register, discharge diagnosis ICD-8 348.0 OR ICD-10 G12.2. Case definition was 1^st^ diagnoses on or after 1/1/1982-12/31/2009. | Evaluated diabetes, obesity, physical/ stress trauma, CVD (1977–2009) and lead, diesel exhaust and solvents | Selected joint predictors and interactions using boosted regression trees and Logic regression, which were included in a logistic regression model adjusting for age, SES, and geography. Model used a 3 year lag. | N = 1086 incident ALS cases, 677 exposed; 111,507 controls | ALS incidence; Low; Large uncertainty regarding exposure assessment (ever/never exposed). Adequacy of 3 year lag is unknown.
Seals et al. (2017) (Denmark) Population-based case-control | Registry-based case identification using the Danish National Patient Register, 1982–2009 (3,650 incident cases). Controls, 4 per case matched on sex, age, and no ALS diagnosis in Hospital Register as of index date obtained from Central Person Registry (All Denmark residents since 1968). | Occupational histories obtained from Danish Pension Fund databases. Used NOCCA (Nordic Occupational Cancer Study)- Danish JEM for periods 1960–74, 1975–84, and 1985 and after. Inputs year and industry code and outputs prevalence of exposure for each job along with expected exposure level (ppm) in exposed. The JEM has not been validated to estimate levels of formaldehyde. Cumulative expected exposure calculated (prevalence multiplied by expected level) summed over jobs and time (3 & 5 year lags). Exposure misclassification expected. | Danish National Patient Register, discharge diagnosis ICD-8 348.0 OR icd-10 G12.2. Case definition was 1^st^ diagnoses on or after 1/1/1982–12/31/2009. | Controls were matched to cases by age, sex and calendar date. Assessed SES (highest attained, 5 groups based on job title), marital status and residence. Other covariates were relative to 4^th^ year before index year: whether worked on that year, years worked prior, hospital admission, # times admitted prior, # admissions, prior diagnoses used to construct Charlson Comorbidity Index. No information on smoking status | Conditional logistic regression adjusted for age, sex, index date, SES, marital status and residence. In secondary analyses included other work variables, # hospital diagnoses, plus Charlson Comorbidity Index. Exposure metrics were dichotomous (ever exposed lagged 3 years), quantiles, and continuous | N = 3650 incident cases, 1,068 exposed; 14,600 controls | ALS incidence; Medium; Uncertainty regarding exposure assessment. JEM not validated to predict formaldehyde exposure level.
Fang et al. (2009) (United States) General population (case-control) | Sequential ALS cases recruited, 1993-1996, from 2 major referral centers in New England; eligibility criteria cases & controls: lived in New England at least 50% of year, mentally competent, English speakers; 71% of eligible cases participated; controls by random telephone screening, frequency matched on sex, age (3 groups), & region; 76% of eligible (256 of 270 completed questionnaire). | Occupational history by structured questionnaire; industry, occupation, frequency and duration; jobs held before ALS diagnosis or 2 years before interview (controls); formaldehyde- exposed occupations identified a priori by industrial hygienist; calculated life-time hours of exposure weighted by probability in specific jobs | Diagnoses by board-certified specialists in motor neuron disease using World Federation of Neurology El Escorial criteria | Adjusted for age, sex, area of residence, smoking (ever/never), & education; no additional workplace exposures associated with ALS | Unconditional logistic regression models; linear trend with lifetime exposure days, probability, & weighted exposure duration (4 categories); effect modification by smoking; missing occupational data for 2/111 cases & 3/256 controls | N = 109 ALS cases (N = 20 exposed) 253 controls | ALS incidence; Medium; Uncertainty regarding exposure assessment; small number of exposed cases
Peters et al. (2017) (Sweden) Nested case-control study | All Swedish births (1901–1970) and included in 1990 Swedish Population and Household census, N=5,763,437. Controls randomly selected (5 per case) from population alive on date of diagnosis, matched on birth year and sex. 25,100 controls. | Occupational history obtained from 1970, 1980, and 1990 census; included occupations listed ≥ 10 years prior to index date; occupational exposures assessed using Swedish version of JEM (Nordic Occupational Cancer Study), prevalence and level of exposure at specific calendar time. Exposure metric for dose response, prevalence multiplied by annual mean level for each occupation at time of census (mg/m^3^), averaged across all censuses; dichotomized at median in controls | Linkages to National Patient Register, primary or secondary diagnosis, ICD-9 335C or ICD-10 G12.2 (inpatient visits 1991-2010 and outpatient visits 2001–2010); follow-up to date of first visit, migration, death, or 12/31/2010. 5,010 cases | Addressed age and sex via matching, adjusted for education and evaluated 12 of >20 agents possibly associated with ALS. No adjustment for smoking status although restriction to blue collar workers and farmers may have partially addressed potential confounding | Conditional logistic regression, OR and 95% CI, adjusted for education and other 11 chemicals; restricted analyses to cases and controls with at least one occupation listed in any census and to blue-collar workers or farmers; sensitivity analysis restricting to < 65 years at index date, age of retirement | 2,647 cases (n=323 exposed), 13,378 controls | ALS incidence; Medium; Uncertainty regarding exposure assessment
Pinkerton et al. (2013) (United States) Garment workers (cohort) | Cohort of garment workers (N=11,098) exposed for ≥ 3 mos at 3 facilities (late 1950s to early 1980s). | Monitoring in 1980s, geometric mean 0.15 ppm (GSD 1.9 ppm), constant levels across departments and facilities, year of first exposure (42% before 1963), time since 1^st^ exposure (median 39.4 years) and exposure duration (median 3.3 years). Exposure levels prior to 1980 not assessed. | Vital status ascertained through 2008, ICD-10 G12.2, ICD-9 335.2, ICD-8 348.0, and ICD-7 356.1; ALS mortality is a good surrogate for ALS incidence | Adjusted for age, calendar time, sex, race; no information on smoking. Mortality for COPD and lung cancer in cohort was similar or greater than national rates suggesting possible bias away from null. | Life table analysis, excluded missing birth date (n-55), deaths (n=8), loss to follow-up prior to rate file begin date (n=13); SMRs and 95% CI | N = 11, 022 414,313 person-years at risk; 8 ALS deaths | ALS mortality; Medium; Small number of cases. Confounding by smoking away from null not of concern because effect estimates were null.
Roberts et al. (2016) (United States) National Longitudinal Mortality Study. Occupational (cohort); Note: same laboratory and data handling procedures as Weisskopf et al. (2009) | 794,541 men and 674,694 women (recruitment date unclear, but study from 1973–2011) aged 25+ at recruitment (national).; Follow-up time provided by participants.; Internal comparison, participation unlikely to be influenced by knowledge of exposure and disease. | Self-reported at enrollment based on survey regarding last or most recent job. Exposure matrix constructed by industrial hygienists at the National Cancer Institute. Metrics included intensity and probability of exposure. No information about duration in job. Information on other exposures not col lected/reported. | ALS Mortality (National Death Index from 1979–2011) as underlying cause; ICD-9 code 335.3 (specific for ALS) or ICD-10 code G12.2(forall motor neuron diseases, of which ALS comprises the overwhelming majority) | Adjusted for education, race/ethnicity, and income (participants tended to be poorer, less educated, and less frequently non-Hispanic white. One sensitivity analysis among high probability, high exposure group (all funeral directors) included adjustment for smoking and military service. | Data handling and analysis as in Weisskopf et al. (2009) HRs provided for each exposure intensity and probability for men and women separately. Additional sensitivity analyses to evaluate validity of exposure and outcome assignments and selection bias, included follow up restricted to 75 years or excluding first 5 years, age restricted to 35–75 or 50–75 years at enrollment, or restricted to those employed at enrollment. Did not provide or incorporate any data on duration. | N = 472 deaths in men (100 exposed); 285 deaths in women (61 exposed). N = 2 in jobs with high probability and intensity of formaldehy de exposure | ALS mortality; Medium; Uncertainty regarding exposure assessment, including the influence of duration, no information about job history prior to most recent job; very small number of exposed cases (n=2 in jobs with high probability and intensity of formaldehyde exposure)
Weisskopf et al. (2009) (United States) American Cancer Society Cancer Prevention Study II.; General population (cohort) | 987,229 (414,493 men, 572,736 women) enrolled in 1982. National recruitment; no major illness at baseline, not missing age or sex data. Follow-up from 1989 through 2004.; Internal comparison, participation unlikely to be influenced by knowledge of exposure and disease. | Self-reported, mailed questionnaire in 1982. Current or past regular exposure to formaldehyde and duration (years) (not specified, but likely in occupational settings).; Data on 10 other types of chemicals and X-ray exposure also collected. | Mortality (National Death Index), underlying or contributing cause; ICD-9 (1989–1998) code 335.3 or ICD-10 (1999–2004) G12.2. (ALS represents > 98% of these categories) | Adjusted for age, sex, smoking, military service, education, alcohol, occupation (farmer, lab technician, machine assembler, programmer), vitamin E use, and the other chemical (and X-rays) exposures assessed at baseline. | Cox proportional hazards modeling, analyzed with and without approximately 1/3 who reported exposure but did not provide duration data (i.e., less likely to be truly exposed). | N = 1,156 ALS deaths (36 exposed) | ALS mortality; Medium; Uncertainty regarding exposure assessment
Neurobehavioral tests and olfactory detection
Broder et al. (1988c) (Canada; Toronto) Residences (household survey) Additional reference: Broder et al. (1988b); Broder et al. (1988a) | Homes with UFFI insulation, within 60 miles of Toronto. 4,400 of 8,200 agreed to be contacted; 95% participated. Control homes randomly selected from streets adjacent to UFFI homes, 20% participated. Some demographic and symptom data allowed comparison with nonparticipants; similar neighborhood, demographics. | 2-day samples in homes, 5 hr/d Median ppm Control 0.031 UFFI 0.038; No exposure contrast | Sense of smell threshold for pyridine; three control bottles (mineral oil only) plus 3 bottles with 0.00005, 0.008, and 0.012% pyridine. Replicate tests conducted. Variability and stability of test kits assessed. Participant blinded. | Detailed demographic data collected | Prevalence by group and Chi-square test. | N = 1,726 from UFFI homes, 720 from control homes | Sense of smell; Not informative; No appreciable difference in median exposure between groups
(Wilmer et al., 1989): Kilburn et al. (1985b); Kilburn et al. (1987); Kilburn etal. (1989b) (United States) Workers: histology technicians (survey) | Recruited from attendees (female) at annual histology technician conferences, 1982 and 1983. Participation rate not reported. Potential for participation based on knowledge of exposure and symptoms. | Self-reported hours per day (based on detection of odor) | Neurobehavioral test battery (memory, cognition, spatial relation integration, dexterity, conceptual motor speed, balance, reaction time); 1 hour | Adjusted for age, number of cover slipped slides (for other solvent exposure), duration of smoking | Multiple regression. Coefficients and designation if p < 0.05 (no standard errors) | N = 305 | Neurobehavioral tests; Low; Potential selection bias (could be influenced by perceived exposure and effects), limited detail presented in results
Kilburn and Warshaw (1992) (United States) Workers: histology technicians (survey, multiple time points) | Recruited from attendees (female) at annual histology technician conferences, 1982, 1983, 1985, 1986, 1989. Participation rates not reported. Potential for participation based on knowledge of exposure and symptoms | No information on intensity or frequency of exposure | Neurobehavioral test battery (memory, cognition, pattern recognition, dexterity, decision making, motor speed, balance); 2–3 hrs | Considered age, sex, number of cover-slipped slides (for other solvent exposure), years of exposure | For analysis of single (first) test per subject (n=350), reported as “not statistically significant.” For longitudinal analysis (n=19), no decline in performance noted (formaldehyde exposure not explicitly analyzed). | N = 19 with 4 tests, 299 with 2 or 3 tests, 350 with one test | Neurobehavioral tests; Low; Potential selection bias, limited detail presented in results. Longitudinal analysis limited by sample size and did not specifically address formaldehyde exposure
Kilburn (2000) (United States, 6 states). Home or office exposure (survey) | Exposed (e.g., new mobile homes or renovated offices), experienced “adverse effects almost daily”; referent group randomly selected from voter registration rolls in 4 cities (location and participation rate not reported). | No exposure measures. | Neurobehavioral test battery | Frequency matched by age and education | Mean ±SD percent prediction | 20 exposed, 202 referents | Neurobehavioral tests; Not informative; Likely selection of exposed based on symptoms; no exposure measures, limited covariate data.
Schenker et al. (1982) (United States) Residences (survey) | People self-referred to occupational and environmental health clinic regarding health effects of formaldehyde insulation. No comparison group. | Measured in 4 homes (protocol not described), ranged from 0.03 to 0.23 ppm | Neurobehavioral battery | Not addressed | Prevalence | 18 adults, 6 children (from 6 homes) | Neurobehavioral tests; Not informative; Likely selection of exposed based on symptoms; limited exposure measures, no comparison group

#### Controlled Exposure Studies in Humans

Table B-50 Evaluation of human controlled exposure studies of formaldehyde - nervous system effects

Reference, setting, and design | Exposure assessment (quality descriptor and exposures; see Appendix B.3.1) | Outcome classification | Consideration of possible bias (randomized exposure order, blinding to exposure) and confounding | Analysis and completeness of results | Size | Confidence
Andersen and Molhave (1983) ^a^ | Chamber type and analytical concentrations not provided; testing during exposure (distractibility likely contributes); 4 d of exposure | Endpoints limited: sparse methods on conduct of partial neurobehavioral test battery | Exposure order by Latin square design; blinding not indicated | Comparisons appear to represent pooled sexes; results data NR | n=16 | Low; Test batteries performed during exposure (irritation anticipated to result in distracted responses), an incomplete set of tests, blinding not reported, and reporting deficiencies.
Bach et al. (1990) | Test article not defined (inferred from related studv, (Andersen and Molhave, 1983))^c^; testing during exposure (distractibility likely contributes); acute (5.5 hr) exposure | Endpoints limited: sparse methods on conduct of partial neurobehavioral test battery | Occupation exposure group and controls from population registry (attempted matching by age, education, smoking prevalence but workers had higher smoking and lower education; details not reported); Exposure order by balanced Latin square design; blinding not indicated | Results reporting incomplete & difficult to decipher | n=61 males only | Low; Test batteries performed during exposure (irritation anticipated to result in distracted responses), incomplete set of tests, blinding not reported, and reporting deficiencies.
Lang et al. (2008) ^a^ | “Quasi-static” exposure chambers; testing immediately after exposure; study focus on irritation; no indication of acclimation; recovery not examined (reaction time); 10 d of exposure | Endpoints limited: decision reaction time | Exposure order randomly assigned double blinded | Data= combined sexes; high variability in reaction time data | n=21 ≈20% attrition | Medium Limited set of tests; high attrition rate

a Atthe request of EPA’s Office of Chemical Safety and Pollution Prevention, EPA’s Human Studies Review Board review of four intentional exposure studies for potential use in assessing acute formaldehyde inhalation determined the ethical conduct of this study to be adequate.

#### Animal Toxicology Studies

Animal studies in Table B-51 are grouped by endpoint type, and then organized alphabetically by first author. Specific study details (or lack thereof) that highlight a limitation or uncertainty in answering each of the domain criteria are noted in the table cells. For those identified as having a substantial limitation likely to influence the study results (major limitations), the relevant study details are bolded. Italics are used to highlight other limitations not viewed as substantial in the context of nervous system effects (minor limitations). A ‘Good’ domain rating is denoted by ‘++’; an ‘Adequate’ rating by ‘+’; and a ‘Deficient’ rating by gray shading.

Table B-51 Evaluation of controlled inhalation exposure studies examining nervous system in animals

Reference | [underlined: Exposure quality]^a^ (see Appendix B.3.1) | Test subjects | Study design | Endpoint evaluation | Data considerations & statistics | Confidence Classification
Odorant or Irritant Detection/Effects
(Apfelbach and Weiler, 1991) | +; Chamber type not specified | +; N = 5 (exposed) or 10 (controls); males only | Testing during exposure; controls not air-exposed in exposure chamber; possible continuous exposure; Note: 130 d exposure | Training started 30d after exposures began(not clear if training ability prior to endpoint testing was affected) | ++ | Not informative [Tested during exposure; missing controls; training during exposure]
(Wood and Coleman, 1995) | ++ | +; N = 8; males only | Testing during exposure; each animal served as its own control (multiple exposures/animal); acute exposure (60 seconds on/off for ≈1hr) | ++; Note: endpoint is not adverse (irritant detection) | ++; Note: statistical comparisons not possible | N/A^*^; Olfactory detection/irritation response; [Tested during acute exposure]
Cursory Examinations in Long-Term Toxicity & Carcinogenicity Studies
(Appelman et al., 1988) | ++ | +; N ≥ 10; males only | Behaviors tested during exposure; study focus not nervous system-specific; 1 year study | +; Endpoints limited to cursory cage-side observations, gross pathology, & weight | Results data NR; behavioral effects not quantified | **; [Tested during exposure; study focus not CNS; data NR]
(Coon et al., 1970) | +; Multiple species exposed simultaneously | +; N = 15 (rats); age & sex ratio/group not given Dogs (N = 2) deficient | Behaviors tested during exposure; study focus on overt toxicity and inflammation; 90 d study | Endpoints limited: cursory cage-side observations & brain sections “retained” (not clear if examined) | Results data NR; behavioral effects not quantified; one death noted, but no cause provided | Not informative; [Tested during exposure; limited endpoints; data NR]
(DHGC, 2010) | Formalin (high concentration: methanol may drive responses) | N = 3-6 | Behaviors tested during exposure; acute exposure | Endpoints limited: cursory observations of behavior during exposure | Effects not quantified | Not informative; [Tested during exposure; limited endpoints; data NR; High formalin levels; small N]
(Kerns et al., 1983)^b^ See also (Battelle, 1982) and (Swenberg et al., 1980b) | ++ | ++; N = 10 | Behaviors appear to have been tested immediately after exposure; study focus on carcinogenicity; Note: based on a 2 year GLP-compliant study | +; Endpoints limited to simple neurofunctional observations & gross pathology; methods provided in the full GLP report indicate lack of observer blinding | Results data NR in published article; latency NR; data in the full GLP report is qualitative (normal vs. abnormal) & is pooled across test battery endpoints | **; [Tested immediately after exposure; study focus not CNS; data NR]
(Maronpot et al., 1986) | Formalin | ++; N=10 | Behaviors tested during exposure; study design not nervous system-specific; 13 wk study | +; Endpoints limited to cursory cage-side observations & gross pathology | Results data NR; behavioral effects not quantified | Not informative; [Formalin; tested during exposure; study focus not CNS]
(Morgan et al., 1986a) | +; Analytical concentrations not provided | N = 3–6; males only | Behaviors tested during exposure; study design not nervous system-specific; acute exposure | Endpoints limited: cursory observations of distress during exposure | No quantified neurological effects | Not informative; [Formalin; small sample size; tested during exposure; data NR; small N]
(Tobe et al., 1985b; Tobe et al., 1985a) | Formalin (Note: methanol control group included in the chronic study) | +; N = 3–20 (depending on the experiment, endpoint & exposure group); males only | Behaviors tested during exposure; study design not nervous system-specific Note: studies of variable duration (up to 28 mos) | +; Endpoints limited to cursory cage-side observations; gross pathology, brain wt. weight also performed in 28-month study | Results details NR for many experiments & animals; behavioral effects not quantified; multiple dead animals could not be examined for comparisons due to decomposition | **; [Formalin: controlled for some endpoints; tested during exposure; data NR]
(Woutersen et al., 1987) | +; Animals were housed in the inhalation chambers | ++; N=40 | Behaviors tested during exposure; study design not nervous system-specific Note: 13 wk study | +; Endpoints limited to cursory cage-side observations, brain wt. | Results data NR; behavioral effects not quantified | **; [Tested during exposure; data NR]
Neuropathology
(Aslan et al., 2006) | ++ | N= 3 litters (5 pups); males only; dam health during lactation & pup health not presented Note: possible subset of Songur et al. (2003) study; same animals as Sarsilmaz et al. (2007) study^e^ | +; Unclear if potential litter bias was corrected (although randomized treatment groups); dams seemed to be co-exposed with pups from PND 1–14; Note: 30 d of exposure | ++; Note: regional or hemisphere volume changes not verified by immunostaining, leaving interpretations unclear; sensitive stereology methods; random sampling indicated | As presented, data do not account for potential litter effects (pup means presented) | Medium; [Small sample size; potential for litter bias]
(Bian et al., 2012) | Formalin (high concentration: methanol may drive responses) | N= 3/endpoint/time point; males only; mild toxicity: decreased food intake (effect not quantified) | Controls not air-exposed in exposure chamber; all groups had anesthesia & antibiotic injections; exposures = 1 hr/d; Note: 90 d exposure; single exposure level | +; Number of slides/animal not provided; relatively insensitive method for cell count quantification Note: blinding & other methods appropriate | ++ | Not informative; [High formalin levels; small N; insufficient controls]
(Liu et al., 2010) | Formalin (high concentration: methanol may drive effects)/static chamber | +; Group size for staining not clear; males only; groups determined by preexposure probe trial performance | +; Exposures only 30 min twice daily; 28 d | Potential sampling bias: details on blinding, slides/animal, etc. not provided; imaging specifics not provided and qualitative only | +; Hippocampal Nissl staining not quantified | Not informative; [High formalin levels; potential sampling bias]
(Mei et al., 2016) | Formalin | +; N = 8; males only | +; No comparisons to chamber or air exposure alone; 8 hr/d for 7 consecutive days | Potential sampling bias: details on blinding, slides/animal, etc. not provided; qualitative only | No quantitative results (e.g., counts; severity scores; etc.) | Not informative; [formalin; potential sampling bias; no results quantification]
(Pitten et al., 2000) | Formalin/static chamber | +; N = 5–8; Note: no changes in body weight were observed | +; Exposures only 10 min/d for 90 days | Potential sampling bias: details on blinding, slides/animal, etc. not provided; qualitative only | Results data NR | **; [Formalin; potential sampling bias; data NR]
(Sarsilmaz et al., 2007) | ++ | N = 3 litters (5 pups); dam health during lactation & pup health not presented; males only^c^; Note: possible subset of Songur (2003) study; same animals as Aslan et al. (2006) study^c^ | +; Unclear if potential litter bias was corrected (although randomized treatment groups); dams seemed to be co-exposed with pups from PND 1–14; 30 d of exposure | ++; Note: regional or hemisphere volume changes not verified by immunostaining, leaving interpretations unclear; sensitive stereology methods; random sampling indicated | As presented, data do not account for potential litter effects (pup means presented) | Medium; [Small sample size; potential for litter bias]
(Songur et al., 2003) | +; Analytical concentrations not provided | N = 6 pups (likely 3 litters); mild toxicity (body weight changes at 30 & 60 d, but not 90 d^d^); males only | +; Unclear if potential litter bias corrected (& not indicated as randomized); 30 d of exposure | Cell counting methods do not detail how many slides/animal were examined (may be a single slide) | as presented, data do not account for potential litter effects (pup means presented) | Low; [Small sample size; potential for sampling and litter bias]
(Wang et al., 2014a) | Mixture (formalin, benzene, toluene and xylene)/static chamber | ++; N = 12 males/group Note: no changes in body weight were observed | ++; 2 hr/d exposure for subchronic (90 d) | Relative, but not absolute (preferred), brain weights were reported; number of H&E samples NR; Note: both insensitive | ++ | Not Informative; [Mixture exposure only; non-preferred results presentation]
Neural Sensitization-Related Responses
(Sheveleva, 1971); (translation) | Test article not defined (assumed to be formalin) | +; Use of mongrel white rats; N = 7 dams or 6 offspring/sex evaluated from 6 litters, so assumed 1 pup/sex/litter examined, but not specified; unclear why 7 dams vs. 6 offspring | +; Latency between dam exposure and testing not provided: unclear if reflex bradypnea can influence these measures (e.g., reduced respiration leading to transiently reduced O_2_ content in muscle tissue, causing reduced excitability); 4 hr/d exposures from GD1–19 | “Neuromuscular excitability” protocol specifics not provided (e.g., blinding; how assessed) | +; Statistical methods used were not specified; data appear to account for possible litter effects, but not clearly described | Low; [Formalin; endpoint methods NR]
(Sorg et al., (1996) | Formalin (high concentration: methanol may drive responses) | +; N ≥ 4; females only | Potential high concentration irritation-related responses (that may affect odor discrimination in tasks involving exploration) were not measured; exposure 1 hr/d for 7 d; Note: single exposure level | +; Overall plus maze activity not provided; Note: questionable human relevance of rodent sensitization responses | +; Groups divided into high & low responders for presentation of most endpoints & statistical comparisons; statistical comparisons NR for 1-month recovery data | Not informative; [High formalin levels; possible confounding by irritation]
(Sorg et al., 1998) | +; Chamber type not provided; declining HCHO exposures across days | +; N= 15–24; females only | +; Imprecise timing of assessment; unclear effect of prior cocaine exposure/handling on nociception (assumed to be minimal); Note: 1 or 4 wk exposure; single exposure level | Experimenter blinding not indicated; methods for measuring vertical activity NR in cited reference; Note: questionable human relevance | ++ | Medium; [Blinding NR; limited methods description] Note: relevance of inescapable stress unclear
(Sorg and Hochstatter, 1999) | +; Chamber type and analytical concentrations not provided | +; N = 4; females only (conditioned fear) OR N= 8; males only (approach/avoidance) | Possible effects on olfactory detection of conditioned odors by HCHO nasal effects; Approach/avoidance tested during exposure to formalin vapors; Note: 4 wk exposure; single exposure level | ++; Note: questionable human relevance of rodent sensitization responses | Effects without cocaine NR: (unclear influence of prior cocaine exposure in conditioned fear responses) | Low; [Unclear influence of changes in olfactory detection or prior cocaine exposure]
(Sorg et al., 2001b) | +; Chamber type and analytical concentrations not provided | +; N = 7–8 | Testing during exposure; exposures ≤ 4 wk; Note: single exposure level | +; Methods for measuring vertical activity NR in cited reference (but automated using photocell counts) | ++ | Low; [Tested during exposure; limited methods reporting]
(Sorg et al., 2002) | Formalin (likely high concentration- not quantified: methanol may drive responses); HCHO levels NR | +; N = 6–12 | Formalin used as an aversive stimulus- results more specific to cocaine; behaviors evaluated coincident with exposures; acute exposure | Tests involve odor detection & irritationspecific responses: could confound results Note: questionable human relevance | Specific effects of formaldehyde alone on behaviors NR; some data presented with groups divided into high & low responders for statistical comparisons | Not informative; [High formalin levels; likely confounding by irritation and odor; missing controls]
(Sorg et al., 2004) | +; Chamber type not specified | +; N = 7–8 | Possible effect on olfactory detection of conditioned odor by HCHO nasal effects; context testing prior to conditioned fear tests may cause order effects; Note: single exposure level; 4 wk exposure | +; Possible contribution of change in footshock sensitivity not examined Note: questionable human relevance of rodent sensitization responses | ++ | Low; [Unclear influence of changes in olfactory detection]
(Usanmaz et al., 2002) | ++ | +; N = 6; unexplained overt toxicity (body weight decrease) with multiple exposures | Observations immediately after exposure; acute (3 hr) or short-term (1–3 wk) exposure | Observations not blinded; 5 min test duration; peripheral vs. central square crossings not measured, limiting interpretability | ++ | Low; [Tested immediately after exposure; no blinding]
Motor Activity, Habituation, and Anxiety (& Aggression)
(Boja et al., 1985)^e^ | +; Analytical concentrations not provided | +; N = 8; males only | Behaviors tested during exposure; acute exposure (3 hr/d for 1–2 d); timing of exposures (9–12 pm vs. 12–3 pm) may not have been same across groups; Note: single exposure level | Appropriateness of protocol for adult animals is questionable (methods designed for pups); “active” vs. “nonactive” endpoint readout is nonspecific | +; Statistical comparisons to aironly exposure groups NR for all treatment groups; higher exposure groups data NR and text suggests results are somewhat inconsistent | Low; [Tested immediately after acute exposure; endpoint methods may be inappropriate]
(Katsnelson et al., 2013) | Test article not defined (assumed to be formalin; high concentration: methanol may drive effects) | ++; N= 12–15 females/group | Testing indicated as immediately after exposure; Note: subchronic (10 wk) exposure | Protocols not specified, although hole board test methods assumed to be conducted in a standard manner; blinding not indicated | ++ | Not informative; [High levels of test article assumed to be formalin; irritation effects likely]
(Li et al., 2016) | Formalin; static chambers | +; N = 15 (inferred); males only | +; Testing began ≈2 hr postexposure; Note: exposure 2 hr/d for 7 d | Blinding not indicated for all tests except forced swim: of particular concern for nonautomated novel object testing; unclear impact of multiple tests in same animals (chosen test order may reduce impact); % open time in EPM does not include % closed time; note: slight body weight loss 2.46 mg/m^3^ | ++ | Low; [Formalin; endpoint evaluations fail to control for several important variables]
(Liu et al., 2009a) | Formalin (high concentration: methanol may drive effects)/static chamber | +; N = 8; males only | +; 14 d exposure; Note: tested >24 hr after exposure; | Spontaneous locomotor activity was assessed subsequent to aggression tests, which may influence anxietyrelated responses; blinding not indicated | ++ | Not informative; [High formalin levels; test order concerns]
(Malek et al., 2003a) | Formalin | ++; N= 15/sex | +; 2 and 26 hr postexposure; acute: 2 hr | +; 3 min test duration; manual scoring (blinded); peripheral vs. central square crossings not quantified, limiting interpretability | +; Assuming data is SE, some statistical significance calls are questionable; variability unclear: SE reported is higher than SD for same parameters in 2003^b^ | Low; [Formalin]
(Malek et al., 2003b) | Formalin | ++; N= 10/sex | +; 2 hr postexposure; acute: 2 hr | +; 3 min test duration; manual scoring (blinded); peripheral vs. central square crossings not quantified, limiting interpretability | ++ | Low; [Formalin]
(Malek et al., 2004) | Formalin | +; N = 20; males only | +; 2 and 26 hr postexposure; acute; 2 hr | +; 3 min test duration; manual scoring (blinded) | ++ | Low; [Formalin]
(Senichenkova, 1991a) (translation); (Senichenkova, 1991b) | Test article not defined (assumed to be formalin) | Sex, N, & strain NR; could not be evaluated due to lack of reporting | +; Unclear if litter bias corrected; Note: 4 hr/d exposures from GD 1–19; single exposure level | Open field protocol specifics not provided (e.g., blinding; manual vs. automated assessment of activity) | +; Statistical methods NR | Not informative; [Test article assumed to be formalin; test animal and endpoint protocol details NR].
(Sheveleva, 1971) (translation) | Test article not defined (assumed to be formalin) | +; Mongrel white rats; N = 6 offspring/sex evaluated from 6 litters, so assumed 1 pup/sex/litter examined, but this was NR | ++; 4 hr/d exposures from GD 1–19 | “Spontaneous mobility” protocol specifics not provided (e.g., blinding; manual vs. automated assessment of activity) | +; Statistical methods NR | Low; [Test article assumed to be formalin; missing endpoint protocol details].
(Sorg et al., 1998) | +; Chamber type not provided; declining HCHO exposures across days | +; N = 15–24; females only | +; Imprecise timing of assessment & unclear effect of prior exposure to cocaine/handling on plus maze endpoints (assumed to be significant); Note: 1 or 4 wk exposures; single exposure level | Experimenter blinding not indicated (note: activity measures automated); overall plus maze activity not provided; unclear impact of saline injection, handling; methods for measuring vertical activity NR in cited reference | ++ | Activity; Medium; [Blinding NR; limited methods description; unclear impact of prior manipulations]; Plus maze; Low; [Blinding NR; limited methods description; overall activity NR; test order concerns]
(Sorg et al., 2001b) | +; Chamber type and analytical concentrations not provided | +; N = 6; males only | +; No EEG/EMG sham controls and influence of 37% formalin irritation responses NR; exposures ≤ 4 wk; Note: single exposure level | No pre-formaldehyde sleep measures; sleep pattern methods NR Note: questionable adversity of endpoints | ++ | Low; [limited methods reporting; preformaldehyde comparisons NR] Note: questionable adversity
(Usanmaz et al., 2002) | ++ | +; Unexplained overt toxicity (body weight decrease) with multiple exposures; N = 6 | Observations immediately after exposure; acute (3 hr) or short-term (1–3 wk) exposures | Observations not blinded; 5 min test duration; peripheral vs. central square crossings not measured, limiting interpretability | ++ | Low; [Tested immediately after exposure; lack of blinding]
Learning and Memory
(Chonglei et al., 2012) | Mixture (formalin, benzene, toluene and xylene)/static chamber | +; N = 5 males/group | +; Testing 30 min after exposure; 2 hr/d exposure for short term (10 d) | Path length or similar NR (contribution of motor effects not tested); visual cues NR; no blinding indicated | ++ | Not informative; [Mixture exposure; endpoint protocol deficiencies]
(Liao et al., 2010) (translation) | Formalin/static chamber | N = 8: pooled sexes (N = 4/sex); overt toxicity during exposure (e.g., listlessness; up to ≈30% decreased body weight gain), most likely from deficient exposure quality, as only 0.5 mg/m^3^ HCHO | Latency not provided (assumed that observations made immediately after exposure); no indication of correction for possible litter bias; Note: exposures 2 hr/d for 28 d | Path length or similar NR (contribution of motor effects not tested); pool temperature, pool diameter, & platform size NR; recovery time between escape latency trials not indicated; no blinding indicated | +; Data= combined sexes (test often displays sex differences) | Not informative; [Formalin; overt toxicity; endpoint timing and protocol deficiencies]
(Liu et al., 2010) | Formalin (high concentration: methanol may drive effects)/static chamber | +; Males only; treatment groups determined by performance in preexposure probe trials, but unclear exactly how groups were matched; Note: N = 8–11 | +; Latency for all assessed time points unclear, but appears that most had ≥24 hr habituation period between exposure and training/testing; exposures only 30 min twice daily; 28 d exposure | ++; Note: probe trials preexposure were comparable; cued trials conducted to rule out HCHO effects on vision | ++ | Not informative; [High formalin levels; static chamber]
(LICM, 2008) | Unspecified wood (possible co-exposures not tested) | +; N = 5; males only | Training behaviors assessed 30 min postexposure and possible indirect effects of irritation on training may influence performance in the probe trial test; 7 d exposure | +; Path length or similar NR (contribution of motor effects not tested); no blinding indicated | +; Comparisons across treatment groups NR for probe trial test | Low; [Likely mixture exposure; possible impact of irritation]
(Mei et al., 2016) | Formalin | +; N = 8; males only | +; No comparisons to chamber or air exposure alone; testing 3 hr after exposure during training; Note: 8 hr/d for 7 consecutive d | Path length or similar NR (contribution of motor effects not tested); pool temperature, pool diameter, start positions & platform size NR; no blinding indicated (of concern, as not automated; note: cited references did not contain these details) | ++ | Low; [formalin; endpoint protocol reporting deficiencies; lack of blinding]
(Malek et al., 2003c) | Formalin/static chamber | ++; N = 15/sex/group; no changes in body weight were observed | +; Latency 2 hr postexposure; exposures for 2 hr/d for 10 d | Motor effects appear to drive some responses & were not tested (path length or similar NR); possible influence of changes in olfaction and/or vision not tested; blinding not indicated | +; No ANOVA or trend tests performed across the 4 groups (only pair-wise tests) | Low; [Formalin; endpoint protocol deficiencies; no blinding]
(Pitten et al., 2000) | Formalin/static chamber | +; N = 5–8; Note: no changes in body weight were observed | +; 22 hr postexposure; exposures only 10 min/d; Note: 90 d exposure | +; Possible influence of changes in olfaction and/or vision not tested; path length or similar NR | +; Data= combined sexes (test often displays sex differences) | Low; [Formalin]
(Wang et al., 2014a) | Mixture (formalin, benzene, toluene and xylene)/static chamber | +; N = 6 males/group Note: no changes in body weight were observed | +; Testing 30 min after exposure; Note: 2 hr/d exposure for 49–90 d | Path length or similar NR (contribution of motor effects not tested); visual cues NR; no blinding indicated | ++ | Not informative; [Mixture exposure; endpoint protocol deficiencies]
Nociception
(Sorg et al., 1998) | +; Chamber type NR; declining HCHO exposures across days | +; N= 15–24; females only | Imprecise timing of assessment following exposure; unclear if cocaine or saline challenged; Note: single exposure level; 1 or 4 wk exposures | +; Experimenter blinding not indicated | ++ | Medium; [Unclear exposure to testing latency]
Functional Observational Battery or Grip Strength
(Chonglei et al., 2012) | Mixture (formalin, benzene, toluene and xylene)/static chamber | +; N = 5 males/group | +; Unclear exposure to testing latency; 2 hr/d exposure for short term (10 d) | No description of grip strength protocol provided | ++ | Not informative; [Mixture exposure; endpoint protocol NR]
(Tepper et al., 1995) | Carpet emission exposures: formaldehyde not primary exposure (BHT, toluene, etc.) | N= 2 (nonexposed controls) or 4; males only | Behaviors tested immediately after exposure | ++ | Quantitative data NR for the majority of measures; some measures presented as compared to preexposure or summarized qualitatively | Not informative; [Mixture exposure; small sample; likely confounding; selective reporting]
(Wang et al., 2014a) | Mixture (formalin, benzene, toluene and xylene)/static chamber | +; N = 6 males/group Note: no changes in body weight were observed | +; Unclear exposure to testing latency; Note: 2 hr/d for 49–90 d | +; No blinding indicated; Note: 5 s inter-trial delay and 3 trials/d | ++ | Not informative; [Mixture exposure]
Electrophysiology (for Hazard; see below for MOA)
(Bokina et al., 1976) | Details of exposure were not provided | Details on test subjects were not provided | Details of study design were not provided | Details of endpoint measures were not provided | No quantitative comparisons to controls were performed | Not informative; [Experimental details NR]
(Katsnelson et al., 2013) | Test article not defined (assumed to be formalin; high concentration: methanol may drive effects) | +; N = 12–15/group; females only | +; Testing indicated as immediately after exposure: unclear if RB-related effects could affect these impulses Note: subchronic (10 wk) exposure | ++; Note: Citation for temporal summation of impulses protocol was provided | ++ | Not informative; [High levels of test article assumed to be formalin]
Autonomic Effects (for Hazard; see below for usefulness for MOA)
(Nalivaiko et al., 2003) | Unregulated exposure without reporting of levels; no chamber Note: paraformaldehyde | +; N = 6–13; males only | No nonexposed groups indicated (internal comparisons); acute exposure; All animals implanted with electrodes (duration before tests NR) | +; ECG implantation procedures NR Note: endpoint not considered adverse | ++ | Not informative; [Exposure levels NR and unregulated; missing controls]
(Tani et al., 1986) | Formalin (high concentration: methanol may drive responses) | +; N = 4–5; males only | No nonexposed groups indicated (internal comparisons); acute exposure; all animals received anesthesia, surgery, and anticoagulants (no recovery before exposure) | Blocker experiments may be influenced by prior exposure to formaldehyde Note: endpoint not considered adverse | +; Effects of blocker experiments without prior HCHO exposure NR | Not informative; [High formalin levels; missing controls; test order concerns]
(Yu and Blessing, 1997) | Formalin (likely high concentration- not quantified: methanol may drive responses); HCHO concentrations NR | +; N = 5–16; males only | No nonexposed groups indicated (internal comparisons); acute exposure; all animals received surgery, anesthesia, and catheterization 1 wk prior to exposure | ++; Note: Endpoint not adverse | +; Data were pooled across groups for some measures; Note: all comparisons to preexposure measures | Not informative; [Formalin levels NR; missing controls]
(Yu and Blessing, 1999) | Test article not defined (assumed to be formalin); levels not quantified (likely high: methanol may drive responses) | +; N = 4; males only | No nonexposed groups indicated (internal comparisons); other alerting & noxious stimuli administered pre-HCHO; 2 surgeries- only 1 d recovery after cannulation before exposure; acute exposure | ++; Note: Endpoint not adverse | +; Justification for selection of resting periods used for comparison unclear; data qualitative only | Not informative; [Test article assumed to be formalin; exposure levels NR; missing controls]

NR = not reported; N/A = not applicable.

* Three studies examined an endpoint that is not adverse and has no MOA relevance. These are briefly mentioned in the assessment, as they inform the irritant/odorant threshold of rodents, but these studies were not used to characterize the potential neurotoxicity hazard.

** Five animal studies sufficient for hazard characterization were not categorized using confidence ratings, and they are not included in the exposure-response array, as they represent cursory observations with none or minimal data reporting; however, these studies were used to help describe the potential neurotoxicity hazard.

a Although some notes on exposure levels are included, considerations and interpretations related to the tested exposure levels are discussed as part of the evidence synthesis in the Toxicological Review, with one exception for tracking “high exposures” when co-exposure to methanol is expected to be a driver of observed responses. For details, see the draft Methanol Toxicological Review (http://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=233771), which proposes an RfC of ≈2 mg/m^3^. Assuming methanol is present in the breathing zone somewhere in the range of 1/10–1/3 the levels of formaldehyde when stabilized formalin solutions are used as the test article (determination of the exact ratio of exposure is not currently available), exposures > 10 mg/m^3^ are interpreted as “high exposure” and assumed to have at least some methanol-driven effects.

b Kerns is a report of a GLP study by CIIT (Battelle, 1982), which was not identified in the literature search [Note: use of GLP or guideline study protocols is provided to identify the most stringent studies but did not factor into the confidence ratings or sufficiency evaluations for this database].

c Communication with the study author detailed those male rats (2 per litter from 3 separate dams per dose group) were used in the (Sarsilmaz et al., 2007) study. A review from this same laboratory (Songur et al., 2010) indicated that the stereological studies of the hippocampus were conducted to confirm previous observations (Songur et al., 2003); thus, the separate reports of stereological changes in the CA and DG regions of the hippocampus (Sarsilmaz et al., 2007) and (Aslan et al., 2006), respectively) are assumed to represent the same cohort of animals (note: it is possible that these two stereological studies report effects on a subset of the same animals used in the (Songur et al., 2003) study, but this inference is less clear and is not assumed).

d Note: although pup body weight changes would be of concern as potential confounders for behavioral analyses, endpoints such as neuropathology and brain weight are unlikely to be secondary to these changes: at least for brain weight, the current literature does not support a consistent causal relationship. In (Songur et al., 2003), body weight decreases were ≈10% and 20% at 30 d (low and high formaldehyde concentrations, respectively) & ≈10% at 60 d (high concentration only).

e Because data for exposure groups other than 6.15 mg/m^3^ were not reported by (Boja et al., 1985), the higher exposure groups were not included in the study quality analysis or the Toxicological Review hazard ID synthesis.

#### Mechanistic Studies Related to Nervous System Effects

This review constrained the mechanistic studies considered relevant to the potential nervous system effects of inhaled formaldehyde to experimental studies of inhalation exposure (see Table B-52). Thus, the methods and documentation applied paralleled those described above, with a few exceptions in application (i.e., acute exposure duration and the ability to infer the endpoint as adverse were not considered limitations, and within endpoint evaluation consideration was given to whether the endpoint evaluates a mechanism relevant to humans, although mechanisms are considered relevant to humans in the absence of evidence to the contrary).

Table B-52 Evaluation of studies pertaining to mechanistic events associated with nervous system effects

Reference | Exposure quality^a^ (see Appendix B.3.1) | Test subjects | Study design | Endpoint evaluation | Data considerations & statistics | MOA Confidence Classification
(Ahmed et al., 2007) | ++ | +; N = 4–5; females only | Lack of OVA-free controls: inability to separate effects of OVA & formaldehyde; possible altered distribution/effectiveness of aerosolized OVA given after formaldehyde; Note: 12 wk exposure; single exposure level | ++ | ++ | Medium; [Control group deficiencies]
(Bian et al., 2012) | Formalin (high concentration: methanol may drive effects) | N = 3/endpoint/timepoint (males); mild toxicity: decreased food intake (effect not quantified) | Controls not air-exposed in exposure chamber; all groups had anesthesia & antibiotic injections; Note: exposure 1 hr/d for 90 d; single exposure level | ++ | ++ | Not informative; [High formalin levels; Small N; missing control]
(Boja et al., 1985) | +; Analytical concentrations NR | +; N = 8; males only; data from experiments with N = 1 (air-HCHO NE & DA levels) not included in the assessment | +; Timing of exposures (9–12 pm vs. 12–3 pm) may have varied across groups; Note: single exposure level; acute exposure: 3 hr/d for 1–2 d | +; Molecular verification of regional “punches” not performed | +; Higher exposure groups data NR; inability to evaluate findings for exposures indicated as tested but NR | Medium; [Selective reporting; some methods detail NR]
(Bokina et al., 1976) | Details of exposure were not provided | Details on test subjects were not provided | Details of study design were not provided; Note: continuous exposure for 45d | Details of endpoint measures were not provided | No quantitative comparisons to controls were performed | Not informative; [Experimental details NR]
(Fujimaki et al., 2004b) | +; Analytical concentrations NR | +; N = 5–6; females only; unclear influence of splenic effects (e.g., decreased weight) | +; For OVA groups: unclear if prior formaldehyde exposure had nasal effects influencing inhaled OVA booster distribution/effects; Note: 12 wk exposure | +; Methods for ELISA of plasma NR: assumed to be same as BAL fluid ELISA | ++ | Medium; [Control group deficiencies; some methods detail NR]
(Fujimaki et al., 2004a) | +; Analytical concentrations NR | +; ELISA data: N = 5; males only; RT-PCR data: N = 3; (considered major limitation) | +; for OVA groups: unclear if prior formaldehyde exposure had nasal effects influencing inhaled OVA booster distribution/effects; 12 wk exposure | Methods for brain dissection & homogenization, as well as gel quantification NR; ELISA and booster challenge methods NR | ++ | ELISA; Medium; RT-PCR; Low; [Control group deficiencies; small sample size; some methods detail NR]
(Gieroba et al., 1994) | Formalin (likely high concentration- not quantified: methanol may drive response) | N = 2 or 6 | Unclear contribution of apnea & bradycardia; results may be specific to exposure combined with restraint & anesthesia; strong irritation induced | +; Number of sections analyzed/animal NR | Immunostaining results were not quantified across groups; results are qualitative only; TH^+^ | Not informative; [High formalin levels; small N; possible confounding]
(Hayashi et al., 2004) | ++ | +; N = 5; females only | ++; Exposures up to 12 wk | +; Possible mild sampling bias (3 sections, but selection methods NR); blinding indicated | ++ | Medium; [Small N; limited sampling]
(Kimura et al., 2010) | Formalin | N = 5–6; males only; systemic toxicity not evaluated (HCHO tested up to ^≈^55 mg/m^3^) | +; Irritation-related effects probable, as tested nearsimultaneous with exposures; acute exposure; unclear if anesthesia/dye injection influenced sensory nerve responses | +; Blinding not indicated for cell type counts | ++ | Low; [Formalin; possible overt toxicity; small N]
(Kulle and Cooper, 1975) | +; Analytical concentrations NR | N = 3; males only; no air-only controls | +; All animals underwent surgery prior to exposure (no recovery prior to exposure); some exposures were complicated by amyl alcohol co-exposure; acute exposure | ++; Note: unclear relevance of these surgical preparations to human nerve responses | No quantitative comparisons to controls performed (extrapolated threshold only) | Low; [small sample size; comparison group deficiencies]
(Chonglei et al., 2012) | Mixture (formalin, benzene, toluene, and xylene)/static chamber | +; N = 5 males/group | ++; 2 hr/d exposure for short term (10 d) | No description of hippocampal MDA and GSH protocols provided | ++ | Not informative; [Mixture exposure; protocols NR]
(Li et al., 2016) | Formalin; static chambers | +; N = 7 (inferred); males only | ++; 2 hr/d exposure for short term (7 d) | +; Some sampling bias possible: 3 sections; Note: although not corrected for neuron number, location determined from atlas; slides were randomized and coded for blinded evaluation | ++ | Low; [Formalin]
(Liao et al., 2010); (translation) | Formalin/static chamber | N = 8: pooled sexes (N = 4/sex); overt toxicity during exposure (e.g., listlessness; up to ≈30% decreased body weight gain), most likely from deficient exposure quality, as only 0.5 mg/m^3^HCHO | +; No indication of correction for possible litter bias; Note: 2 hr/d for 28 d | Potential sampling bias: N = 5 fields (assumed to be per animal), but number of slides not indicated (DAB amplification used) & no correction made to account for the number of neurons visible/field | +; Data= combined sexes; CA3 cell number or viability measures NR | Not informative; [Formalin; endpoint protocol deficiencies; overt toxicity]
(Liu et al., 2009a) | Formalin (high concentration: methanol may drive effects)/static chamber | +; N = 5; males only | ++; 28 d exposures | ++ | ++ | Not informative; [High formalin levels]
(Liu et al., 2010) | Formalin (high concentration: methanol may drive effects)/static chamber | +; N=5; males only; treatment groups determined by preexposure probe trial performance, but method for matching groups NR | ++; 28 d exposures | Methods for quantification of western blots NR | ++ | Not informative; [High formalin levels; protocols NR]
(LICM, 2008) | Unspecified wood | +; Sample sizes for MOA-related endpoints were NR, but assumed to be N = 5; males only | ++; 7 d exposures | Regional brain dissections were nonspecific & methods incompletely described; RT-PCR analyses were semi-quantitative only | ++ | Low; [Possible mixture exposure; endpoint protocol description insufficient]
(Matsuoka et al., 2010) | Formalin | +; N = 7–9; males only | +; Did not appear that controls were air-exposed in chambers (“noninhalation controls”); acute exposure | Methods for brain dissection/regions analyzed NR; assumed brain region-specific analyses were not conducted | +; High variability in measures, possibly due to lack of regional specificity | Low; [Formalin; endpoint protocol description insufficient]
(Mei et al., 2016) | Formalin | +; N = 8; males only | +; No comparisons to chamber or air exposure alone; 8 hr/d for 7 consecutive d | No blinding for biochemical measures; no regional specificity (homogenates) | ++ | Low; [formalin; some endpoint protocol limitations]
(Nalivaiko et al., 2003) | Unregulated exposure without reporting of levels; no chamber; Note: paraformaldehyde | +; N = 6–13; males only | +; No nonexposed groups indicated (internal comparisons); all animals were implanted with electrodes, but duration prior to testing not provided; acute exposure | +; ECG implantation procedures NR | ++ | Not informative; [Exposure levels NR and unregulated; etc.]
(Ozen et al., 2003b) | +; Analytical concentrations NR | Unclear contribution of unexplained overt toxicity (robust effects on body weight); males only; N = 7 | ++; 4 wk or 13 wk exposures | Methods for analyses of brain tissue were not clearly described, even in cited reference | ++ | Not informative; [Overt toxicity; endpoint protocol description insufficient]
(Sari et al., 2004) | ++ | +; N = 5/endpoint; females only | ++; 12 wk exposure | Cell counts were not reported as observer blinded, but were from serial sections; RT-PCR analyses were semi-quantitative only | ++ | Medium; [possible experimenter bias- no blinding]
(Sari et al., 2005) | ++ | +; N = 5; females only | Nasal instillation of toluene may affect formaldehyde distribution | Cell counts were not reported as observer blinded, but were from serial sections | Data for exposures without toluene NR Note: 2004 paper data cited was not considered | Not informative; [Data on formaldehyde exposure alone NR; no blinding; exposure paradigm concerns]
(Songur et al., 2003) | +; Analytical concentrations NR | N = 6 (assumed 3 litters); mild toxicity (body weight & food/water intake changes): HSP activation may be indirectly related to health/nutrition | +; Litter assignments NR; unclear if litter bias corrected; 30 d of exposure | Potential sampling bias: details on blinding, slides/animal, etc. not provided; nonblinded intensity ratings subject to observer bias | +; No statistical comparisons for HSP staining | Low; [small sample size; possible litter and/or sampling bias]
(Songur et al., 2008) | ++ | Dam health during lactation & pup health not presented; sex and litters/group unknown (likely males & 3 litters); body weights were indicated as measured, but NR; N = 7 pups | +; Unclear if litter bias corrected (& not indicated as randomized); dams exposed from PND 1-14; 30 d of exposure | ++ | ++ | Medium; [Small sample size; possibly litter effects]
(Sorg et al., 2001a) | ++ | +; N = 6–10; males only | +; Possible difference in harvest day (20 vs. 21) across groups may contribute to high variability noted in results; exposures ≤4 wk | +; Volume of trunk blood/animal and some other details (e.g., serum isolation) NR Note: chamber exposure itself (tested) had a large influence, so critical to rapidly remove rats after exposure (as indicated) | ++; Note: sensitive endpoint, so high level of variability is as expected | Medium; [Small sample size; some protocol details unclear]
(Sorg et al., 2002) | Formalin (likely high concentration; not quantified: methanol may drive response) | +; N = 6–12 | Formalin used as an aversive stimulus- results more specific to cocaine; acute exposure to concentrated vapors | Tests involve odor detection & irritation-specific responses could be confounding results | +; Specific effects of formaldehyde alone not tested or NR | Not informative; [Formalin (assumed high level) levels NR]
(Tani et al., 1986) | Formalin (high concentration: methanol may drive responses) | +; N = 4–5; males only | +; No nonexposed groups indicated (internal comparisons); animals received anesthesia, surgery, and drugs with no recovery before exposure; acute exposure | +; Blocker experiments may be influenced by prior exposure to formaldehyde (not tested) | ++ | Not informative; [High formalin levels]
(Tsukahara et al., 2006) | ++ | +; Females only; Western Blot data: N≥ 6; Caspase data: N = 3; (considered major limitation) | +; For OVA groups: unclear if prior formaldehyde exposure had nasal effects influencing inhaled OVA booster distribution/effects; 60 d exposure | ++; (for Western Blot data) Caspase data: likely sampling bias: number of slides/animal & neurons visible/field NR; counts were not reported as observer blinded | ++ | Western blot; Medium; [small N; possible minor confounding]; Caspase; Low; [Caspase data: small sample size; likely sampling bias]
(Wang et al., 2014a) | Mixture (formalin, benzene, toluene, and xylene)/static chamber | +; N = 6–12; males only; Note: no changes in body weight were observed | ++; 2 hr/d exposure for subchronic (90 d); tested 1 d postexposure | No description of grip strength protocol provided | ++ | Not informative; [Mixture exposure; endpoint protocol NR]
(Yu and Blessing, 1997) | Formalin (likely high concentration; not quantified: methanol may drive responses) | +; N = 5–16; males | Animals received surgery, anesthesia, & catheterization 1 wk prior to exposures; no nonexposed groups indicated (internal comparisons); acute exposure | ++ | +; Data was pooled across groups for some measures.; Note: all comparisons to preexposure measures | Not informative; [Formalin (assumed high level) levels NR; missing controls]
(Yu and Blessing, 1999) | Test article not defined (assumed to be formalin); levels not quantified (likely high: methanol may drive responses) | +; N = 4; males only | No nonexposed groups indicated (internal comparisons); other alerting & noxious stimuli administered pre-HCHO; 2 surgeries; only 1 d recovery after cannulation before exposure; acute exposure | ++ | +; Justification for selection of resting periods used for comparison unclear; data qualitative only | Not informative; [Unknown test article (assumed to be formalin) levels NR (assumed high level); missing controls]
(Zitting et al., 1982) | Test article results in co-exposures to formic acid, acrolein, & possibly other chemicals | +; N = 4–5; males only | Formaldehyde levels >> 100 mg/m^3^ are overtly toxic (rats gasped for air for hours after exposure); 6 hr or 3 d exposure | +; Evaluations are not brain-regionspecific | +; Details on statistics NR (e.g., “Student’s t test”) | Not informative; [Unknown test article (assumed to be formalin) at high level; overt toxicity]

a Mode-of-action study quality evaluations were conducted in a similar fashion as those described above for hazard identification, with minor adjustments to the types of experimental details considered for meeting sufficiency criteria (e.g., adversity of the endpoint was not considered).

b A mechanism or mode of action is considered relevant to humans unless there is convincing evidence to the contrary.

### B.3.8 Developmental and Reproductive Effects

Details of the study evaluation approach methods are provided in Section 2.3.8 of the Toxicological Review. As discussed in that section, these reviews focused on human epidemiology and experimental animal studies. Within Tables B-53 (epidemiology studies in residential and occupational settings) and Table B-54 (animal studies) below documenting the results of the study evaluations for developmental and reproductive effects, studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating.

#### Epidemiology Studies

Table B-53 Evaluation of observational epidemiology studies of formaldehyde - reproductive and developmental outcomes

Reference, setting, and design | Consideration of participant selection and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and completeness of results | Size | Confidence
Residential Studies
Amiri and Turner-Henson (2017); (Southeastern United States) Cross sectional study | Pregnant women in 2^nd^ trimester (convenience sample, n = 140) recruited from obstetrics and gynecology clinics with no history of chronic disease or high-risk pregnancy, 19–40 years old, Participation 63% (n = 88). Lower participation rate. | Participants wore vapor monitor badges, 24-hr period, detection limit 0.003 ppm.; Mean (SD) 0.04 (0.06) ppm = 0.049 (0.074) mg/m^3^. This is a measure of total exposure from indoors and ambient air. | Ultrasonographic biometry during 2^nd^ trimester for head circumference, abdominal circumference, femur length, biparietal diameter, estimated fetal weight, and ratio of abdominal circumference to femur length. Measurements in mm converted to percentiles using gestational age and the Hadlock formulas. Sensitivity and specificity for IUGR are 67% and 93% for BPD, 42% and 100% for HC, 94% and 100% for AC and 46% and 90% for AC/FL ratio. Hadlock formulas are based on a sample of White women in the US with uncertain accuracy for other races. Over 50% of the participants were not White. | Urine cotinine adjusted for urinary creatinine (spot sample, methods and timing of collection were not described). Models adjusted for maternal demographics, obstetric history, and cotinine. Biometry measurements were not correlated with maternal age, education, marital status, yearly family income or employment status. No correlation with gravida, maternal smoking, or pregnancy intervals. BPD was lower among whites compared to AfricanAmericans or other category. BPD and FL varied by sex. | Multiple linear regression for formaldehyde as dichotomous variable (cutoff at 0.03 ppm) adjusted for maternal age, fetal sex, and race. Mediation of tobacco smoke (urinary cotinine) on associations examined. | N = 88 | Ultrasonographic biometry measurements; Low; Convenience sample, sampling frame not described. Lower participation rate. Small sample size. Reference population for BPD measure was not appropriate for >50% of participants.
Chang et al. (2017) (Birth cohort) South Korea; Mother and Childrens Environmental Health Study | Pregnant women were selected from cohort (n = 383), originally recruited from hospital; information on demographics and housing characteristics via questionnaire. Infants followed at 6 (n=262), 12 (n=234), 24 (n=199), and 36 months (n=92). Notable attrition from study. | Personal formaldehyde measurements during mid- or late pregnancy, 3 d. Categorized into two groups below and above the 75^th^ percentile and also continuous with log transformation. Mean (SD) 0.082 (0.052) mg/m^3^, geometric mean 0.067, 75^th^ percentile 0.106 mg/m^3^. Correlation between TVOCs and formaldehyde 0.22, p<0.01. | Age-specific weights by gender using growth standard for Korean children. | Prenatal variables from questionnaire and medical records; postnatal via questionnaire and interview. ETS slightly higher in low formaldehyde group but was not associated with weight. | Analyzed birth weight adjusted for maternal age, pre-pregnancy body mass index, education level, parity, gender, gestational age at birth and residential factors. Analyzed postnatal weight at each visit using multiple linear mixed models adjusted for gender, birth order, breastfeeding and education. | N = 360 singleton newborns | Birth weight; mean difference in weight at 6, 12, 24, and 36 months; Medium; Hospital-based cohort, notable attrition over time
Franklin et al. (2019) (Australia) Birth cohort | Pregnant women, all nonsmokers, recruited prior to 18 wks gestation. Recruited 373 women, 305 (81.7%) participated; 4 excluded because of smoking. Birth data available for 262 live births (70.2% of recruited). | Air monitoring in homes at 34 wks gestation, 7-d sampling duration using validated passive samplers in bedroom and living room. LOD 2.4 μg/m^3^; used LOD/2 for values < LOD.; House average Median (range) 2.81 (LOD – 17.33) μg/m^3^; 23.3% < LOD. Uncertainties in exposure distribution due to proportion < LOD. | Gestational age, birth weight, birth length and head circumference from birth records. | Confounders were selected based on previous literature. Adjusted for maternal age, parity, maternal asthma, diabetes and blood pressure, season of birth. Distance from main road and ETS exposure were evaluated as potential confounders in models. Adjusted and unadjusted results presented. | Gestational age was normally distributed. Birth weight, birth length and head circumference were transformed to z-scores (accounting for sex and gestational age). General linear models. | N = 262 | Gestational age, birth weight, birth length, head circumference; Medium; Uncertainties in exposure distribution due to proportion < LOD, and analysis as continuous variable.
Occupational Studies
(Axelsson et al., 1984) (case-cohort) laboratory work | University laboratory workers identified via payroll (born 1935 and after, worked in lab 1968–1979); 95% response; birth register records compared for respondents and nonrespondents. | Self-report (Y/N) during 1st trimester, open question; likely exposure misclassification, no information on intensity or frequency of exposure | Spontaneous abortion & birth defects; self-report & birth registry, 1968–1979. Spontaneous abortion verified using hospital records or via recall. | Miscarriage rate not associated with smoking before or during pregnancy (raises uncertainty about data quality); inverse association of solvent exposure with pregnancy number, age, and work shift | Unadjusted analyses for formaldehyde | Only N = 10 exposed pregnancies; potentially unstable risk estimates | Spontaneous abortion Birth defects; Not Informative; Open-ended question unreliable for exposure classification; uncertainty regarding data quality: miscarriage rate higher in nonresponders and not associated with smoking
Ericson et al. (1984) (nested case control) | Controls (2 per case) selected from other infants in registry born in 1976 of laboratory worker; 50% of cases and 20% of controls responded about exposure | Lab work identified by occupational code in 1975 census; self-report on work during pregnancy & exposure to agents (open question); potential misclassification; no information on intensity or frequency of exposure | Perinatal deaths (< 7 d) & birth defects; National Birth Register, 1976 | Controls selected randomly within same age (5-year categories) and parity stratum as case. No information on smoking or other risk factors. | Unadjusted analyses for formaldehyde | N = 3 exposed cases | Perinatal deaths Birth defects; Not Informative; Open-ended question unreliable for exposure classification; low response regarding exposure; very few exposed cases
Hemminki et al. (1982) (cohort) hospital staff | Recruited from nursing staff working in sterilizing units (exposed to sterilizing agents, x-rays, or anesthetic gases) or auxiliary units (referent) in all general hospitals; Response > 90% for both exposed and referent; recall likely not related to exposure on intensity and frequency. | Exposure (Y/N) at beginning of pregnancy to specific agents assigned by supervising nurse, blind to case status, possible exposure misclassification, particularly for earlier years. No information | Spontaneous abortion: self report on pregnancies, 1951–1981; questionnaire & hospital discharge register | Regression adjusted for several risk factors and presented risk estimates for other sterilants (ethylene oxide, glutaraldehyde). Formaldehyde results not adjusted for other sterilants. | Binary logistic regression for exposure (yes/no) adjusted for ge, parity, decade of pregnancy, smoking habits, alcohol, and coffee consumption | N = 50 exposed pregnancies (6 spontaneous abortions); 1,100 unexposed pregnancies (121 spontaneous abortions) | Spontaneous abortion; Low; Assumed sterilant use was same throughout period; no information on intensity and frequency of formaldehyde exposure (exposure misclassification—decreased sensitivity); no adjustment for other sterilants; adjustment for parity may introduce bias; small number exposed cases
Hemminki et al. (1985) (case control) nursing staff | Birth outcomes from national discharge register linked to national occupational register. Occupation identified for > 87% of exposed and referent. Selected hospital nurses. | Occupation during 1st trimester identified by head nurses at all general hospitals in Finland plus exposure (Y/N) to listed substances (used sterilizing agent or sterilized instruments; formaldehyde included in list); potential exposure misclassification; no information on intensity or frequency. | Spontaneous abortion & birth defects, 1973–1979; hospital discharge register linked to personnel register | Referent with healthy birth selected from same hospital as cases; matched on age; not adjusted for other risk factors or other workplace exposures | Conditional logistic regression. Unadjusted OR presented for FA; no statistical tests | N = 6 exposed cases for spontaneous abortion 3 exposed cases for birth defects | Spontaneous abortion and birth defects; Low; No information on intensity or frequency (exposure misclassification—decreased sensitivity); very small number of exposed cases
John et al. (1994) (case control) cosmetologists | Recruited from license registry (currently and formerly employed), 74% with eligible pregnancy, data obtained for 71.5% of cases, 74% live births; restricted analysis to full-time workers during 1^st^ trimester. | Self-report; response to closed list (Y/N & frequency of use), no ambient measurements; relevant exposure period: 1st trimester; pregnancies while full-time cosmetologist | Spontaneous abortion, 1983 – 1988, most recent pregnancy (decreased sensitivity because of time-lapse bias). Self-report verified by positive pregnancy test or medical care | Regression adjusting for several risk factors plus other work exposures among full-time cosmetologists | Adjusted OR, 95% CI, unconditional logistic regression adjusting for previous pregnancy loss, mother’s age at conception, & mother’s cigarette smoking during 1^st^ trimester | N = 67 cases, 351 controls | Spontaneous abortion; Medium; Selection of most recent eligible pregnancy (decreased sensitivity); no ambient measurements but exposure assessment was specific to formaldehyde and frequency of use; adjustment for previous pregnancy loss may introduce bias
Lindbohm et al. (1991) (registry linkage) paternal occupation | Identified all pregnancies between 1/1/76–12/31/77 and 5/1/80–4/30/82, excluded maternal age < 12 and > 50 year and missing data on occupation, industry or SES | Industry/occupation code based on national census; assignments by industrial hygienist (IH) using database on chemical exposures and concentrations; potential misclassification into low and mod/hi, and exposure window during spermatogenesis for paternal exposure | Spontaneous abortion identified in hospital discharge register that occurred during a 2-year period close to census | Adjusted for age, SES, & maternal exposure | Linear logistic regression adjusted for age, SES, and maternal exposure to reproductive hazards; risk odds ratio comparing exposed to unexposed | N = 7,772 unexposed SA, 820 potential low, 139 moderate/hi gh | Spontaneous abortion; Low; Industry/occupation coding has low specificity; potential exposure misclassification and imprecise assignment of exposure period to period of spermatogenesis relevant to identified pregnancy
Saurel-Cubizolles et al. (1993) (cohort, retrospective) operating room nurses | Recruited operating room nurses at 18 hospitals (exposed) and randomly from nurses in other departments from same hospital (unexposed); data collection in both groups conducted the same | Self-reported exposure (Y/N) to anesthetics, formol, & ionizing radiation during 1st trimester. No information on intensity and frequency. Potential for exposure misclassification. | Ectopic pregnancy: self-report by interview. Interviewed 1987–1988 | Exposed and referent matched for age, duration of service, sex, occupation, and hospital. Formol exposure associated with exposure to anesthetics. No info on pelvic inflammatory disease but association with formaldehyde not likely. | Chi-square analysis for formol; no multivariate analyses | N = 15 ectopic pregnancies of 734 pregnancies; 1 exposed case | Ectopic pregnancy; Low; Small sample size and unadjusted analyses. No information on intensity and frequency of formaldehyde exposure (exposure misclassification—decreased sensitivity)
Saurel-Cubizolles et al. (1994) (cohort, retrospective) operating room nurses | Recruited operating room nurses at 18 hospitals (exposed) and randomly from nurses in other departments from same hospital (unexposed); data collection in both groups conducted the same | Self-reported exposure (Y/N) to anesthetics, formol, & ionizing radiation during 1st trimester. No information on intensity and frequency. Potential for exposure misclassification. | Spontaneous abortion and birth defects (malformations ICD9): self-report by questionnaire. First pregnancy in or after 1970; interviewed 1987–1988 | Exposed and referent matched for age, duration of service, sex, occupation, and hospital.; Formol exposure associated with exposure to anesthetics | Chi-square analysis for formol; no multivariate analyses | N = 72 spontaneous abortions (9.4%); 22 pregnancies with birth defects (3.4%); 14 major malformatio ns (2.2%) | Spontaneous abortion and birth defects; Not Informative; No information on intensity and frequency of formaldehyde exposure (exposure misclassification—decreased sensitivity). Possible confounding by other exposures and no adjustment (stronger associations observed for spontaneous abortion and anesthetics and ionizing radiation, but not all birth defects); no consideration of impact of gravidity on risk
Shumilina (1975) (cross sectional) cotton textile workers | Unable to assess; selection & response rate not reported | Range reported; sampling protocol not described; analyzed categories of textile finishers and sorted compared to saleswomen | Reproductive & pregnancy history including LBW. Gynecological exam and self-report; methods NR | Job demands among textile workers and referent (sales women) were different; shift work with standing and elevated ambient temperature for exposed | Prevalence & SD; incomplete | | Reproductive disorders, and complications of pregnancy, low birth weight; Not informative; Reporting deficiencies; potential confounding by conditions in the workplace
Steele and Wilkins (1996) (cohort, retrospective) veterinarians | Recruited from graduation rolls; 85% of eligible graduates. Graduated 1970–1980; survey 1987 | Self-reported exposure (Y/N) to specific agents for specific jobs, defined exposed pregnancy if estimated time of conception occurred during years of job where exposure also was reported. 81% reported exposure to formaldehyde; no information on intensity or frequency of exposure. | Spontaneous abortion occurring for pregnancy started after graduation from veterinary college, < 20-wk gestation, Self-reported | Compared exposed pregnancies to employed women who reported no exposure to formaldehyde or not employed during pregnancy. Adjusted for other risk factors, but not other workplace exposures | Unconditional logistic regression adjusting for maternal age, gravidity, previous SA, alcohol, and smoking. Also evaluated height, previous stillbirth, and previous induced abortions. | 1,757 exposed pregnancies, 482 not exposed | Spontaneous abortion; Low; No information on intensity and frequency of formaldehyde exposure which would likely be variable among veterinarians (exposure misclassification—decreased sensitivity). Adjustment for gravidity and previous spontaneous abortion may introduce bias.
Seitz and Baron (1990) NIOSH Health Hazard Investigation (retrospective cohort) clothing manufacturer | Response: 98% of current employees, 18% of former employees employed 1984 or after. Possible survivor bias. Potential for selection bias for comparisons with pregnancy outcomes while at home (away from null); not a concern for comparisons with employment at other locations during pregnancy. | Air sampling 1987, full shift personal breathing zone for 5 task areas, 14 area samples full shift in several locations; perhaps not representative of earlier years; exposure range: TWA 0.17-0.57 mg/m^3^; job status when pregnancy occurred. | Self-report, questionnaire, pregnancy while working at plant compared to employment at other locations or at home; miscarriage (not defined), birth outcomes, self-report (questionnaire). Former workers sent questionnaire in 1984. | Authors stated no differences among groups for other risk factors including smoking, alcohol, use of medications, and presence of diseases (diabetes) | Compared miscarriage and pregnancy outcomes by employment status when pregnancy occurred (employed at Rockcastle or other) or at home. RR (95% CI), Fisher’s exact test | Pregnancies among current: N = 19 at Rockcastle, 71 other, 206 home | Miscarriage; Not Informative; No comparison group (compared pregnancy history during and not during job but could not account for gravidity in that kind of analysis). Limited exposure assessment for earlier years.
Stücker et al. (1993) (birth weight); (Stücker et al., 1990) (spontaneous abortion) (cohort, retrospective) nursing staff | Recruited all female daytime nursing staff, ≤45 year old and currently working in selected units. 87% response among all daytime nursing staff | Current and previous jobs; self-report by interview; dates of each prior pregnancy and dates of occupational exposure to cytostatic drugs, anesthetic agents, and formaldehyde. Exposure based on exposure during or before the pregnancy. No information on intensity or frequency of exposure. | Self-report by interview (spontaneous abortion, birth weight, small for gestation age). Interview 1985–1986. Mean time since exposed and referent pregnancies, respectively, was 5 and 10 years (potential for differential recall and misclassification?) | Exposed and referent were all female day time nursing staff | No analyses were presented for spontaneous abortion. Linear regression for birth weight & formaldehyde association, adjusted for gestational age; not adjusted for other work exposures; other work exposures (quantitative results not reported, just reported as “not significant”) | N = 348 births among formaldehyd e exposed pregnancies; # of spontaneous abortions not reported | Birth weight spontaneous abortion; Not Informative; Inclusion of exposure before pregnancy of uncertain relevance for birth weight. No information on intensity and frequency of formaldehyde exposure (exposure misclassification—decreased sensitivity).; Quantitative results not presented for formaldehyde for birth weight analysis; no results presented for spontaneous abortion analysis
Taskinen et al. (1994) (case-control) laboratory workers | Recruited from payrolls & union rolls, 82.4% response, reduced likelihood of selection bias; 2 referents per case with a live birth and no registered SA, 4 referents per congenital malformation case, study population restricted to age 20–34 years, referents matched to case for age (24 mos) at conception and year at end of pregnancy | Self-report, focus on 1^st^ trimester; exposed & frequency, reviewed by industrial hygienist; calculated exposure index based on reported quantity used, frequency (# hrs/d and # d/wk), and use of fume hood | Spontaneous abortion: hospital discharge register, 1973–1986 | Smoking, alcohol, and employment status considered a priori, plus other factors (parity, previous miscarriages, febrile diseases during pregnancy and used contraception) with OR > 1.5 or p value < 0.05; no other work exposures; possible confounding by xylene exposure, majority of formalin exposed also exposed to xylene (OR 3.1) | Conditional logistic regression adjusted for factors listed in confounding column. Adjustment for parity and previous miscarriage may introduce bias | N = 206 SA cases, 329 referents; 36 malformatio n cases, 105 referents | Spontaneous abortion; Low; Adjustment for parity and previous miscarriage may introduce bias; lack of adjustment for xylene, an exposure associated with the spontaneous abortion and formalin exposure; evaluation of increasing frequency of use a strength.
Taskinen et al. (1999) (cohort, retrospective) woodworkers | Recruited from woodworker’s union (not only current workers) reducing likelihood of survivor bias, 64% returned questionnaire; evaluated exposure response trend; period of recall 1–11 years. | TWA assigned using measurements and reported time at task, sampling protocol not reported, JEM is a more robust exposure assessment; focused on 6 mos prior to pregnancy for TTP relevant exposure window; evaluated risk by glove use in high exposure group; Exposure range: 0.01–1.23 mg/m^3^. Applied formaldehyde concentrations from a comparable workplace when data was missing (missing data was differential by exposure level; high 31%, moderate 61%, and low 46%) | Pregnancies identified from national birth register 1985–1996; live birth. Analysis limited to first pregnancy filling criteria; TTP (FDR): self-report (question: did woman get pregnant during first menstrual cycle when not using contraception? Second? Or how many mos/years?) Left censoring: excluded 38 pregnancies as a result of contraception failure & 28 whose TTP started before the first job in the branch. any previous SA: Self-report | FDR: Regression adjusting for several risk factors plus phenols, FDR for dusts & wood dusts were > 1 in low exposure category & equal to 1 (1.02 & 0.93) in middle & high categories; SA: reported that other exposures were not associated | TTP: Discrete proportional hazards regression and likelihood ratio test, FDR (95% CI), adjusted for employment, smoking and alcohol consumption, irregular menstrual cycles, and # of children. Spontaneous abortion: Unconditional logistic regression, odds ratios, adjusted for age, employment, smoking and alcohol, # exposed cases not reported | Not exposed; N = 367; Low N = 119; Medium N = 77; High N = 39; N = 52 spontaneous abortion cases (in women with same workplace as time-to-preg nancy analysis) | Time-to-pregnancy; Medium; Expect some error in individual exposure assignments; Spontaneous abortion; Medium; Exposures during critical exposure period(s) for spontaneous abortion were not estimated.; excluded women with no live birth (missing spontaneous abortions to women with no live births)
Taskinen et al. (1999) (cohort, retrospective) woodworkers | Not an optimal design for spontaneous abortion: women with no live births but at risk for spontaneous abortion were not included. | | | | | Not exposed; N = 367; Low N = 119; Medium N = 77; High N = 39; N = 52 spontaneous abortion cases (in women with same workplace as time-to-preg nancy analysis)
Wang et al. (2012) (cohort, retrospective) wood processing | 100% of eligible recruited couples participated; did not describe recruitment or sampling frame; included if married males, Chinese Han ethnicity, had formaldehyde exposure for at least 24 mos; excluded couples with possible nonwork exposure to formaldehyde (i.e., newly remodeled homes), or wives with other exposures to reproductive toxicants & pregnancies prior to formaldehyde exposure | Measurements in factories, monitoring on 3 occasions during different periods; Self-report of workplace, work tasks & hours/day exposed to formaldehyde; daily mean exposure = mean concentration multiplied by % of time exposed to formaldehyde (referenced (Taskinen et al., 1999). JEM is a more robust exposure assessment. Did not report formaldehyde estimates; relevant exposure period: gametogenesis | Prolonged time-to-pregnancy (> 12 mos), spontaneous abortion, birth outcomes (preterm birth, LBW, sex ratio, birth defects); semistructured interview using questionnaire; data analysis for most recent pregnancy; potential under-ascertainment because interviewed male partners.; Left censoring: 106 excluded because wife’s pregnancy began before exposed employment | Exposed and referent matched on age, married men & from same area (salesmen and clerks); exposed and referent were of similar age, BMI, educational level, income, smoking, alcohol, frequency of intercourse. Confounding considered: age, BMI, education, income, smoking, alcohol, and frequency of intercourse. Adjusted for other risk factors but not for other work exposures (e.g., dust, phenols) | Logistic regression, paternal exposure risk; adjusted OR, 95% CI; compared low versus high formaldehyde exposed. Comparison of means (referent, low, and high) exposure, ANOVA; crude and adjusted regression coefficients and 95% Cl; OR and 95% Cl for abnormal sperm parameters; reported results of all analyses | 302 exposed, 305 referents. | Time-to-pregnancy; Medium; Exposure levels not reported (but robust assessment method). Dichotomized time-to-pregnancy in analysis (low sensitivity).; Spontaneous abortion birth defects; Medium; Exposure levels not reported (but robust assessment method). Other workplace exposures in woodworking industry (solvents) have been associated with the spontaneous abortion but not accounted for; analysis of most recent pregnancy: possible selection for live births (time-lapse bias) and possible impact of gravidity on spontaneous abortion risk
Wang et al. (2015); (cohort, retrospective) wood processing, 7 industrial sites | Recruited men Recruited men aged 23-40 years of age, Chinese Han ethnicity, and formaldehyde exposed at least 24 mos. Excluded men who lived in newly built or recently decorated house, men with genital malformations or other chronic diseases. Comparison: age-matched male Han population volunteers living in same area (salesmen and clerks) not exposed to formaldehyde or other reproductive toxicants. | Referenced Wang et al. (2012); sampling: 25-min samples at 3 times on 1 workday, same day as investigation. Exposure information based on workplace, work tasks, work duration and time. Exposure index based on formaldehyde concentration (mean of 3 samples) times exposed work time during workday times exposure duration (years). Two categories with cutpoint at median.; Concentrations: Exposed 0.22–2.91 mg/m^3^, exposure index 4.54–195.08, median 56.55; referent 0–0.02 mg/m^3^. | Semi-structured Semi-structured interview using questionnaire; no change in lifestyle or environments 6 mo prior to semen collection; genital examination. Semen sample within 2 wks of exposure sampling, after a 2–7 d abstinence. Semen analysis within 60 min by 2 technicians using same apparatus (computer assisted semen analysis), blinded. Parameters: semen volume, sperm concentration, total sperm count, sperm progressive motility and total sperm motility; kinematic parameters (WHO, 2010), velocity, linearity, displacement measures. | Addressed via design, sex, SES, education, age. Variables included in models: age, body mass index, education, income, smoking, drinking, and abstinence duration. No evaluation of other organic solvents such as phenol or wood preservatives. | Multiple linear regression of In-transformed semen parameters and logistic regression of abnormal semen parameters; reported results for all parameters analyzed | N = 124 (62.3%) recruited, eligible and agreed to participate. 75 of 199 eligible refused to provide sample. No data for 10, N = 114 N = 81 referents (40.5% of eligible), no semen data for 5, N=76 | Medium; Other workplace exposures in woodworking industry (solvents) have been associated with sperm motility but not accounted for; however otherwise strong design and analysis, including evaluation of increasing exposure-response relationship.
Ward et al. (1984) (cross-sectional) autopsy service | Groups similar: exposed and referent all from university (exposed = autopsy service; referent = other medical branches) | Reported ranges for TWA and concentration; area and personal breathing zone. Exposure range: TWA 0.75–1.62 mg/m^3^ | Sperm abnormalities assessed every 2–3 mos (3 samples collected for standard sperm parameters); hand scoring of morphology (no QC data) | Matched on sex, age, tobacco, alcohol, and recreational drug use | No statistical analyses; EPA could compare prevalence | N = 11 men per exposure group | Sperm parameters; Low; Small sample size; uncertainty regarding reliability of morphology scoring
Zhu et al. (2005) (pregnancy cohort) laboratory work | Danish National Birth Cohort, 30–40% of all pregnancies, first pregnancy and laboratory technician (hospital, university, medical industry, food industry or public services), 77.5% initial cohort; referent teachers, 73.9% initial cohort; entered cohort at weeks 12–25 (median 17) | Self-report at gestational weeks 12–25 (median 17 wks), laboratory work processes during pregnancy and 3 mos before conception; JEM exposure index: exposure level (low or medium assigned to work process by study investigators) times frequency of contact. Formaldehyde: Low: processed human blood or tissues, worked with experimental animals or microorganisms; Medium: prepared slides for microscopy. Exposure index did not include use of protective measures (40–64% used exhaust/flow bench). Exposure tool was not validated for formaldehyde. Potential for exposure misclassification | Self-report of TTP (0–2 mos, 3–5 mos, 6–12 mos, >12 mos); fecundability ratio | Demographic characteristics of laboratory technicians and teachers comparable (maternal age, gravidity, history of spontaneous abortion, smoking, alcohol, BMI, paternal job). Possible confounding by other exposures in lab | Fecundability ratios analyzed within the exposed group (exposure index 1–5 vs. >=6) using discrete-time survival analysis; adjusted for covariates listed in confounding column | Exposed N = 829, referent N = 6,250 | Time-to-pregnancy; Low; Categorized time-to-pregnancy (decreased precision), missed pregnancies that ended before 1^st^ interview.; Variation in probability or intensity of formaldehyde exposure possible for work processes across different types of labs, did not account for large proportion of participants who used protective measures to prevent inhalation exposure. JEM was not validated for formaldehyde.
Zhu et al. (2006) (cohort study) laboratory work | Members of the Danish National Birth Cohort, 30–40% of all pregnancies, first pregnancy and laboratory technician (hospital, university, medical industry, food industry or public services), 95% of eligible; referent teachers, 95% of eligible | Self-report at gestational weeks 12–25 (median 17 wks), laboratory work processes during pregnancy and 3 mos before conception; JEM exposure index: see (Zhu et al., 2005) above. Potential for exposure misclassification. | Birth outcomes: preterm birth, small for gestational age, major malformations | Demographic characteristics of laboratory technicians and teachers comparable (maternal age, gravidity, history SA, smoking, alcohol, BMI, paternal job). Possible confounding by other exposures in lab | Cox regression within the exposed group (exposure index 1–5 vs. ≥6), hazard ratios for fetal loss and malformations; logistic regression, odds ratios for other outcomes; adjusted for covariates listed in confounding column | Late fetal loss: exposed N = 9, unexposed N = 106; preterm birth: exposed N = 41, unexposed N = 317; SGA: exposed N = 80, unexposed N = 700; major malformatio ns: exposed N = 56, unexposed N = 379 | Preterm birth, small for gestational age, major malformations; Low; Variation in probability or intensity of formaldehyde exposure possible for work processes across different types of labs, did not account for large proportion of participants who used protective measures to prevent inhalation exposure. JEM was not validated for formaldehyde.

#### Animal Studies

Animal studies in Table B-54 are organized according to the general outcomes evaluated (i.e., gestation exposures and developmental outcomes and reproductive outcomes) and then listed alphabetically. Specific study details (or lack thereof) that highlight a limitation or uncertainty in answering each of the domain criteria are noted in the table cells. For those identified as having a substantial limitation likely to influence the study results (major limitations), the relevant study details are bolded. Italics are used to highlight other limitations not viewed as substantial in the context of respiratory tract pathology (minor limitations). A ‘Good’ domain rating is denoted by ‘++’; an ‘Adequate’ rating by ‘+’; and a ‘Deficient’ rating by gray shading. Some studies included both apical endpoints and endpoints informing potential MOAs. As was the case for nervous system effects, this review constrained the mechanistic endpoints relevant to the developmental and reproductive effects of inhaled formaldehyde to experimental studies of inhalation exposure. Thus, the methods and documentation applied paralleled those described above, with a few exceptions in application (i.e., acute exposure duration and the ability to infer the endpoint as adverse were not considered limitations, and the endpoint evaluation domain considered whether the endpoint evaluates a mechanism relevant to humans, although mechanisms are considered relevant to humans in the absence of evidence to the contrary).

Table B-54 Study quality evaluation of developmental and reproductive toxicity animal studies

Reference | Exposure quality^a^ (see Appendix B.3.1) | Test subjects | Study design | Endpoint evaluation | Data considerations & statistics | Confidence classification
Gestation Exposures and Developmental Outcomes^i^
Al-Saraj (2009) | Test article = formalin; co-exposure with ivermectin (anhelmintic) | +; N = 7 controls and N = 26 FA-exposed; strain NR | Gestation day not standardized via cesarean section; detailed offspring evaluation methods not provided | Only external examination; no visceral or skeletal evaluation of newborn kits | Exposure during gestation not well-characterized; dose-dependent data in dams and offspring not shown.; Litter incidences of external findings not provided; major confounding factor: coexposure with ivermectin, a known developmental toxicant in rabbits | Not informative; (Co-exposure to ivermectin)
Gofmekler (1968) | Test article NC; generation method, analytical method and concentrations, chamber type NR; exposure regimen poorly characterized | N = 3 males and 12 females/group; source and strain NR | +; Limited study design focused on offspring growth (body weight and organ weight) | +; Methods were poorly described but appeared appropriate for the evaluation of offspring growth | Mean body and organ weight data reported, but no variance provided; statistical methods not described although statistical analysis was conducted. Age at assessment of offspring NR; reproductive (maternal and litter) data not provided; overall limited data reporting. | Low; (Test article NC, small N, exposure generation, animal strain/source NR; limited description of methods; limited reporting)
Gofmekler and Bonashevskaya (1969) | Test article NC; generation method, analytical method and concentrations, chamber type, exposure regimen NR | +; N = 12/group; source and strain NR | +; Limited study design focused on developmental anomalies, offspring reproductive organ weights, and histopathology | +; Methods were poorly described but appeared appropriate for the evaluation of. | Report contained only verbal summary of findings. No quantitative data were included in the paper. | Not informative; (Test article NC, exposure generation, animal strain/source NR; limited description of methods; limited reporting)
Guseva (1973a) | Test article NC; generation method, analytical concentrations NR; chamber type NC; co-exposure with formalin in drinking water | N = 4/group; source and strain NR | +; Limited study design focused on reproductive function, developmental anomalies, and postnatal maturation; gonadotropic response to pituitary emulsions, and testicular nucleic acids | +; Methods were poorly described but some appeared appropriate for the evaluation of reproductive function, developmental anomalies and postnatal maturation; gonadotropic response assay was not a standard testing paradigm | Only nucleic acid quantitative data (mean and variance) were reported; all other results were described verbally; statistical methods not described although statistical analysis was conducted. | Not informative; (Test article NC; oral co-exposure with formalin; low N; some experimental methods and data NR)
Kitaev et al. (1984) ^d^ | Test article NC; generation method, analytical concentrations NR; chamber type NC | +; N = 5–9/group; source NR | +; Limited study design focused on early embryonic development, organ weights, and hormone measures; time of day the hormone measures were taken NR | +; Methods were poorly described but appeared appropriate for the evaluation of early embryonic development, organ weights, and hormone measures | +; Group mean data and variance presented; statistical methods not described although statistical analytical results were described in text. Statistical significance NR for some embryonic outcomes; relative organ weight and hormone measure graphs appeared to be hand-drawn | Low; (Test article NC; limited description of methods)
Kum et al. (2007a) | Test article = formalin; generation method, analytical concentrations NR | +; N = 6/group; source NR | +; Limited study design focused on embryonic and early postnatal body and liver weights and MOA (redox enzymes) | +; Methods were poorly described but appeared appropriate for the evaluation of embryonic and early postnatal body and liver weights | +; Group mean data and variance presented; maternal toxicity not reported | Low; (Formalin; limited description of methods; maternal tox NR)
Martin (1990) | ++; Test article = paraformaldehyde; well characterized exposure methods | +; N = 25 dams/group; source NR | +; Study design described as a “teratology study” although few methods details were provided | Methods were not described; endpoints listed in the statistical methods section appeared appropriate for a screening level evaluation of developmental toxicity | +; Inadequate reporting of quantitative results. No group mean data were presented | Low; (Inadequate reporting of methods and quantitative results)
Monfared (2012) | Test article NC; generation method, analytical methods and concentrations NR | ++; N = 10 dams/group; strain and source were reported | +; Limited study design focused on placental weight, histopathology, and ultrastructural pathology | ++; Methods were appropriate for the evaluation of placental weight, histopathology, and ultrastructural pathology | +; Group mean placental weight data and variance presented; photomicrographs provided; maternal toxicity not reported | Low; (Test article NC; maternal tox: NR)
Pushkina et al. (1968) | Test article NC; generation method, analytical method and concentrations, chamber type, exposure regimen NR | +; N = 10 females/group; strain NR | +; Limited study design focused on ascorbic acid levels in dams, fetuses, and placentas | Limited methodological information provided | +; Group mean ascorbic acid levels and variance presented; statistical methods not described although statistical analytical results were noted in table | Not informative; (Experimental methods NR)
Saillenfait et al. (1989) | Test article = formalin with 10% methanol; well-characterized exposure methods | ++; N = 25 dams/group; strain and source provided | ++; Study design was equivalent to a guideline prenatal developmental toxicity study | ++; Methods well described and appropriate for a screening level evaluation of developmental toxicity. | ++; Group incidence and mean/variance data presented | Low; (Formalin)
(Sanotskii et al., 1976) | Test article NC; generation method, analytical method and concentrations NR; chamber type NC | N = 334 total females (females/group NR); strain and source NR | Limited study design only evaluated pregnant vs. nonpregnant dams (did not evaluate reproductive or fetal parameters) | Limited methodological information provided | Inadequate reporting of methods and results (no primary or mean data presented); statistical methods not described although statistical analytical results were noted in text | Not informative (Experimental methods and data NR)
(Senichenkova, 1991a) (translation); (Senichenkova, 1991b) | Test article NC; generation method, analytical method and concentrations NR; chamber type NC | N = 137 total dams (dams/group NR); strain and source NR | ++; Study design focused on in utero developmental outcomes (mortality, growth, visceral, skeletal outcomes), select open; field neurotoxicity measurements in juveniles, and blood acidbase status | +; Limited methodological information provided for tests conducted; apparent methods appropriate for the evaluation of in utero developmental outcomes. | +; Group mean and variance data presented; maternal toxicity not reported; statistical methods not described although statistical analytical results were noted in tables | Low; (Test article NC; exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods)
Senichenkova and Chebotar (1996a) | Test article NC; generation method, analytical method and concentrations NR; chamber type NC | N = 254 total dams (dams/group NR); strain and source NR | +; Control group co-exposure to ethanol; limited study design focused on in utero developmental outcomes (external anomalies and skeletal delays) and blood acidbase status | +; Limited methodological information provided for tests conducted; apparent methods appropriate for the evaluation of in utero developmental outcomes. | +; Group mean and variance data presented; statistical methods not described although statistical analytical results were noted in tables; maternal toxicity not reported | Low; (Test article NC; exposure generation, animal strain/source, # dams/group, maternal tox NR; limited description of methods)
Sheveleva (1971) | Test article NC; generation method, analytical method NR | +; N = 15 dams/group for C-section, N = 6 dams/group for delivery; strain and source NR | +; Limited study design focused on developmental parameters, body weight spontaneous mobility, temperature, and hematology parameters | +; Limited methodological information provided for tests conducted; apparent methods appropriate for the evaluation of developmental parameters. | +; Group mean and variance data presented; statistical methods not described | Low; (Test article NC; exposure generation, animal strain/source NR; limited description of methods)
Reproductive Outcomes
(Appelman et al., 1988) | ++; Test article = paraformaldehyde; well characterized exposure methods | ++; N = 40 males/group; test animals adequately characterized | ++; Study design focused on comparison of subchronic or chronic exposures to rats with undamaged or clinically damaged nasal mucosa; extensive tissue evaluation | No indication if histopathology was performed on male reproductive organs | Quantitative testes weight data were not presented in the study results. No histopathology findings for male reproductive organs were reported | Low; (No indication if histopathology performed on male repro organs; quantitative testes weights not presented)
Golalipour et al. (2007) | Test article NC; generation method NR; open air exposures (i.e., not a controlled chamber study) | +; N = 4 males/group; test animals adequately characterized | +; Limited study design focused on testis toxicity | ++; Methods were appropriate for the evaluation of testis toxicity. | ++; Group mean data and variance presented | Low; (Test article NC; open air exposures; N = 4/group)
Han et al. (2015) | Test article NC; generation method, analytical method and concentrations NR, static chamber type | ++; N = 10 males/group; test animals adequately characterized | +; Limited study design; focused on testis toxicity and MOA | ++; Methods were appropriate for the evaluation of testis toxicity. | +; Group mean testis weight and seminiferous tubule diameter data reported but variance not presented; quantitative microscopy findings not presented | Low; (Test article NC; exposure generation NR; static chamber used; limited reporting of study results and group data)
Maronpot et al. (1986) | Test article = formalin; well-characterized exposure methods | ++; N = 10/sex/group; test animals adequately characterized | ++; Subchronic study with limited in-life observations and extensive postmortem evaluation | ++; Methods were appropriate for a screening level evaluation of general toxicity following subchronic exposure; no special emphasis on reproductive organs | +; Selected incidence data presented (survival, histopathology); mean body weight data did not include variance; no indication of statistical data analysis | Low; (Formalin; limited reporting of methods and results)
Ozen et al. (2002) | ++; Test article = paraformaldehyde; well characterized exposure methods | +; N = 7 males/group; test animals adequately characterized [Note: substantial weight gain decrease with exposure] | +; Limited study design focused on testis toxicity and MOA | ++; Methods were appropriate for the evaluation of testis toxicity | +; Group mean data and variance presented; preferred reporting is absolute, not relative, testes weight | Medium; (Small N; nonpreferred results reporting)
Ozen et al. (2005) | +; Test article = paraformaldehyde; analytical concentrations NR | +; N = 6 males/group; authors noted effects on food and water consumption but didn’t report magnitude of effect, nor quantified changes in body weight | +; Limited study design focused on testis toxicity (includes Bouins fixation of testes) | ++; Methods were appropriate for the evaluation of testis toxicity | +; Group mean data and variance presented; histology results averaged by group not by animal | Medium; (Small N; limited and incomplete reporting of some important results)
Sapmaz et al. (2018) | ++; Test article = paraformaldehyde; well characterized exposure methods | N =7 adult males; source not identified; strain provided | +; Limited study design focused on testis toxicity and biomarkers of oxidative stress | +; Methods generally appropriate for the evaluation of testis toxicity; however, no indication of blinding and unclear sampling protocol for histopathology endpoints | ++; Group mean data and variance presented | Medium; (Small N; potential for bias in histopathology evaluations)
Sarsilmaz et al. (1999) | +; Test article = paraformaldehyde; analytical concentrations NR | ++; N = 10 males/group; test animals adequately characterized | +; Limited study design focused on testis toxicity | ++; Methods were appropriate for the evaluation of testis toxicity | +; Group mean data and variance presented; unable to determine what the reported SD represents for Leydig cell numbers | Medium; (Inadequate information for quantitative analysis of histopathology data)
Vosoughi et al. (2012); Vosoughi et al. (2013) | ++; Test article = paraformaldehyde; well characterized exposure methods; analytical concentrations reported | ++; N = 12 males/group; test animals adequately characterized | +; Limited study design focused on testis toxicity, sperm measures, and hormone (LH, FSH, T) levels | ++; Methods were appropriate for the evaluation of testis toxicity, sperm measures, and hormone levels (LH, FSH, T) | ++; Group mean data and variance presented | High; (No notable limitations)
Wang et al. (2013) | Test article NC; generation method, analytical method and concentrations NR, static chamber type | ++; N = 10 females/group; test animals adequately characterized | +; Limited study design focused on ovarian toxicity, estradiol (E2) levels, and MOA | ++; Methods were appropriate for the evaluation of ovarian toxicity and E levels | ++; Group mean data and variance presented (graphically) for E2 levels and ovarian weights | Low; (Test article NC)
(Woutersen et al., 1987) | ++; Test article = paraformaldehyde, generation method, analytical methods and concentrations reported, dynamic whole-body chamber | ++; N = 40/sex/group; test animals adequately characterized | ++; 13-wk subchronic study | Report indicates that testes and ovaries were weighed at necropsy; no indication if histopathology was performed on male or female reproductive organs | Quantitative reproductive organ weight data were not presented in the study results. No histopathology findings for reproductive organs were reported | Low; (Limited methods; no data presented)
Xing et al. (2007) | Test article NC; generation method, analytical method and concentrations, chamber type NR | ++; N = 12 males and 24 females/group; test animals adequately characterized | +; Limited study design focused on sperm morphology, reproductive success, and micronucleus assay | ++; Methods were appropriate for the evaluation of sperm morphology and reproductive outcome. | ++; Adequate reporting of reproductive outcome results (group incidence and mean data with variance). Micronucleus data not presented. | Low; (Test article NC; exposure generation, strain NR; high exposure levels)
Zhou et al. (2006) | Test article NC; generation method and analytical concentrations NR, static chamber type | ++; N = 10 males/group; test animals adequately characterized | +; Limited study design focused on testes weight and histopathology, sperm measures, and MOA; co-exposure of one FA-treated group with vitamin E to assess mediation effects | ++; Methods were appropriate for the evaluation of testes weight and histopathology, and sperm measures | ++; Group mean data and variance presented (graphically for testes weights); appropriate statistical analysis of data. Vitamin E co-exposure group not included in dose-response assessment for FA outcomes | Low; (Test article NC, exposure generation NR; static chamber used)
Zhou et al. (2011a) | Test article NC; generation method, analytical method and concentrations NR; static chamber type, exposure regimen poorly described | ++; N = 10 males/group; test animals adequately characterized | +; Limited study design focused on testes and epididymal weight and histopathology, sperm measures, testosterone (T) levels, and MOA | ++; Methods were appropriate for the evaluation of testes and epididymal weight and histopathology, sperm measures, and T levels | ++; Group mean data and variance presented (graphically for T levels) | Low; (Test article NC; exposure generation NR; static chamber used)
Zhou et al. (2011b) | Test article NC; generation method, analytical method and concentrations NR; static chamber type, exposure regimen poorly described | ++; N = 12 males/group; test animals adequately characterized | +; Limited study design focused on epididymal weight and histopathology, sperm measures, and MOA | ++; Methods were appropriate for the evaluation of epididymal weight, histopathology, and sperm measures | ++; Group mean data and variance presented (graphically) | Low; (Test article NC; exposure generation NR; static chamber used)

NR = Not Reported; NC = Not Characterized.

### B.3.9 Cancer

Details of the study evaluation approach methods are provided in Section 2.3.9 of the Toxicological Review. Some additional considerations specific to documenting the review of the human studies are outlined below. Within the tables documenting the results of the study evaluations for certain immune-mediated conditions, studies are arranged alphabetically. Gray shading is indicative of aspects of the study design or analysis that decreased EPA’s confidence rating.

#### Human Studies

##### Study Exposure Assessment Methods Categorization

Table B-55 categorizes the exposure assessment methods used in the available human cancer studies.

Table B-55 Categorization of exposure assessment methods by study design

Group | Cohort (and nested case-control within cohort) studies | Case-control and cancer registry-based studies
A | Industrial settings with extensive industrial hygiene data used to determine levels of exposure (and variability within a worksite); job exposure matrix that accounts for variability by time and job/task.; - (Beane Freeman et al., 2009; Beane Freeman et al., 2013); Highly exposed professions (embalmers) with comparison to general population, or with measures capturing variability within the cohort.; - (Hauptmann et al., 2009); - (Hayes et al., 1990); - (Levine et al., 1984c); - (Meyers et al., 2013); - (Stroup et al., 1986); - (Walrath and Fraumeni, 1983); - (Walrath and Fraumeni, 1984) | Detailed lifetime job history, more extensive than industry and occupation codes, including information about specific tasks and setting, combined with job exposure matrix that accounts for variability by time, setting, and job/task. Also includes some kind of validation study or congruence of ratings based on different exposure ascertainment measures to be equivalent to Group A cohort studies with extensive industrial hygiene data.; - (None identified)
B | Industrial settings with more limited industrial hygiene data.; - (Andjelkovich et al., 1995); - (Coggon et al., 2003; Coggon et al., 2014); - (Edling et al., 1987b); - (Fryzek et al., 2005); - (Marsh et al., 2002; Marsh et al., 2007); - (Ott et al., 1989); Exposed professions (e.g., pathologists) with comparison to general population, but that do not have measures capturing variability within the cohort.; - (Bertazzi et al., 1986); - (Hall et al., 1991); - (Harrington and Oakes, 1984); - (Li et al., 2006); - (Matanoski, 1989) | Detailed lifetime job history, more extensive than industry and occupation codes, including information about specific tasks and setting, combined with job exposure matrix that accounts for variability by time, setting, and job/task.; - (Armstrong et al., 2000); - (D’Errico et al., 2009); - (Gérin et al., 1989); - (Gustavsson et al., 1998); - (Hildesheim et al., 2001); - (Pesch et al., 2008); - (Vaughan et al., 2000)
C | Industrial settings that are only able to use duration as a way to distinguish variability in exposure.; - (Band et al., 1997); - (Dell and Teta, 1995); - (Pira et al., 2014); Self-report of exposure.; - (Boffetta et al., 1989); - (Saberi Hosnijeh et al., 2013); - (Stellman et al., 1998) | Lifetime job history coding based only on industry and occupation; more detailed information about specific tasks and setting not included in assessment of exposure potential (or, information on what was collected was not provided).; - (Blair et al., 2001); - (Laforest et al., 2000); - (Luce et al., 2002); - (Olsen et al., 1984); - (Olsen and Asnaes, 1986b); - (Roush et al., 1987); - (Shangina et al., 2006); - (West et al., 1993); - (Wortley et al., 1992); - (Yu et al., 2004); Self-report of exposure.; - (Mayr et al., 2010); Lifetime job history, including tasks/exposure information, but analysis conducted only for job categories rather than for an exposure category; - (Teschke et al., 1997)
D | Industrial settings that do not include data to distinguish variability in exposure (e.g., wood workers, with no information on which workers were exposed to formaldehyde; textile workers with no formaldehyde exposure measures), or that include few people classified as exposed.; - (Hansen et al., 1994) pharmaceuticals; - (Hansen and Olsen, 1995) plant used 1 kg/person/year; - (Jakobsson et al., 1997) grinding stainless steel; - (Malker et al., 1990) fiberboard plants; - (Siew et al., 2012) any occupational exposure; - (Solet et al., 1989) pulp and paper mills; - (Robinson et al., 1987) plywood mill workers; - (Wesseling et al., 1996) banana plant workers; Methods of exposure assessment rated as higher quality but downgraded due to methods used by study authors which were likely to induce bias.; - (Checkoway et al., 2015) | Job history limited to information on a single job (e.g., based on tax record, death certificate, medical record, census data).; - (Heineman et al., 1992); - (Pottern et al., 1992); - (Talibov et al., 2014); High proportion (> 40%) of next-of-kin interviews.; - (Vaughan, 1989); - (Vaughan et al., 1986a); - (Vaughan et al., 1986b); - (Yang et al., 2005); Methods of exposure assessment rated as higher quality but downgraded due to invalidation by study authors.; - (Berrino et al., 2003)

##### Outcome-Specific Confidence Classifications

An outcome-specific evaluations classified with High confidence in the precise effect estimate is expected to be without appreciable bias and thus represents an accurate estimate of any reported association between formaldehyde exposures and the risks of cancer. These evaluations are expected to have methodological features sufficiently sensitive to provide an adequate basis for interpreting null or weak results as evidence of no or weak risk of cancer. Table B-56 identifies the outcome-specific evaluations were classified with High confidence.

Table B-56 Outcome-specific effect estimates classified with High confidence

Reference | Outcome-specific effect estimates | Confidence classification
(Beane Freeman et al., 2009) | Hodgkin Lymphoma | High
(Beane Freeman et al., 2009) | Laryngeal cancer | High
(Beane Freeman et al., 2013) | Lymphocytic leukemia | High
(Beane Freeman et al., 2009) | Multiple myeloma | High
(Beane Freeman et al., 2009) | Myeloid leukemia | High
(Beane Freeman et al., 2013) | Nasopharyngeal cancer | High
(Hauptmann et al., 2009) | Multiple myeloma | High
(Hauptmann et al., 2009) | Myeloid leukemia | High
(Meyers et al., 2013) | Multiple myeloma | High
(Meyers et al., 2013) | Myeloid leukemia | High

An outcome-specific evaluation classified with Medium confidence in the precise effect estimate may have some potential for residual bias, but the direction of the observed effect is unaffected and the magnitude of any expected biases are limited. Thus, the observed effect estimates represent a reasonable estimate of the association between formaldehyde exposures and the risk of cancer, and are expected to be sufficiently sensitive to provide an adequate basis for interpreting null or weak results as evidence of no or weak risk of cancer. Table B-57 identifies the outcome-specific evaluations were classified with Medium confidence.

Table B-57 Outcome-specific effect estimates classified with Medium confidence

Reference | Outcome-specific effect estimates | Confidence classification
(Beane Freeman et al., 2009) | Hodgkin lymphoma | Medium
(Beane Freeman et al., 2009) | Lymphocytic leukemia | Medium
(Beane Freeman et al., 2013) | Sinonasal cancer | Medium
(Coggon et al., 2014) | Myeloid leukemia | Medium
(Coggon et al., 2014) | Laryngeal cancer | Medium
(Coggon et al., 2014) | Oro/hypopharyngeal cancer | Medium
(Gérin et al., 1989) | Hodgkin lymphoma | Medium
(Hayes et al., 1990) | Multiple myeloma | Medium
(Hayes et al., 1990) | Myeloid leukemia | Medium
(Hauptmann et al., 2009) | Lymphatic leukemia | Medium
(Hildesheim et al., 2001) | Nasopharyngeal cancer | Medium
(Meyers et al., 2013) | Oro/hypopharyngeal cancer | Medium
(Walrath and Fraumeni, 1983) | Myeloid leukemia | Medium
(Walrath and Fraumeni, 1984) | Myeloid leukemia | Medium
(Laforest et al., 2000) | Oro/hypopharyngeal cancer | Medium
(Luce et al., 2002) | Sinonasal cancer | Medium
(Olsen and Asnaes, 1986b) | Sinonasal cancer | Medium
(Olsen et al., 1984) | Nasopharyngeal cancer | Medium
(Roush et al., 1987) | Nasopharyngeal cancer | Medium
(Roush et al., 1987) | Sinonasal cancer | Medium
(Vaughan et al., 2000) | Nasopharyngeal cancer | Medium
(West et al., 1993) | Nasopharyngeal cancer | Medium

An outcome-specific evaluation classified with Low confidence in the precise effect estimate is likely to have some residual bias or may lack sensitivity to provide an adequate basis for interpreting null or weak results as evidence of no or weak risk of cancer. For example, an outcome-specific effect estimate based on fewer than five observed or expected cases of a particular cancer would be classified with Low confidence based on a lack of sensitivity, even if there were no appreciable biases. Another study classified with Low confidence might have relied on exposure assessment methodologies that were unbiased, but nonspecific in nature so as to yield effect estimates that were likely biased towards the null, and thus, underestimated any true effect. Similarly, the lack of consideration of latency is a limitation as it may cause measurement error in improperly including exposure of little biological relevance to cancer occurrence. Concern about the potential for confounding is a limitation when a co-exposure is a known cause of a particular cancer endpoint and may be correlated with formaldehyde exposure is a study. Selection bias may be a limitation when survival rates are long as incidence cases may not be readily detected using mortality statistics. In general, outcome-specific effect estimates that underestimate any true effect may still inform a hazard conclusion. However, outcome-specific effect estimates that overestimate any true effect cannot inform a hazard conclusion and are considered to be uninformative as are outcome-specific effect estimates, which suffer from strong bias or a complex mixture of biases.

##### Studies Judged to be Uninformative for the Evaluation of Causation

In rare circumstances, studies initially judged to be potentially informative were further evaluated and found to be uninformative. For example, studies of specific LHP subtypes, which mention formaldehyde or study the health of workers in an industry expected to be exposed to formaldehyde, but details of the study reveal only extremely limited exposure (Dell and Teta, 1995; Armstrong et al., 2000) or virtually none at all (Li et al., 2006). Two outcome-specific associations were judged to be uninformative due, in part, to potential manifestations of the healthy worker effect with standardized mortality ratio for “all cancers” more than 30% below expected values (SMR<0.7: (Harrington and Oakes, 1984; Hall et al., 1991)). Another reason was that a study had co-exposures that are likely to have been highly correlated with formaldehyde and were known risk factors for LHP cancers and the independent effect of formaldehyde cannot be inferred (e.g. (Fryzek et al., 2005; D’Errico et al., 2009). Studies with co-exposures to known risk factors for LHP cancers that are not likely to be highly correlated for formaldehyde or were not risk factor for the specific LHP subtype in question are included and the potential for confounding is noted for evaluation in the causal synthesis. Table B-58 identifies the outcome-specific evaluations were classified as not iformative.

Table B-58 Outcome-specific effect estimates classified as not informative

Reference | Outcome-specific effect estimates | Confidence classification | Critical limitation(s)
(Armstrong et al., 2000) | Nasopharyngeal cancer | Not informative | Multiple
(Berrino et al., 2003) | Laryngeal cancer | Not informative | Confounding
(D’Errico et al., 2009) | Sinonasal cancer | Not informative | Confounding
(Dell and Teta, 1995) | Nasopharyngeal cancer | Not informative | Sensitivity (minimal exposure)
(Fryzek et al., 2005) | Hodgkin lymphoma | Not informative | Confounding
(Fryzek et al., 2005) | Multiple myeloma | Not informative | Confounding
(Hall et al., 1991) | Hodgkin lymphoma | Not informative | Selection bias (healthy worker effect)
(Hansen et al., 1994) | Hodgkin lymphoma | Not informative | Information bias (minimal exposure)
(Hansen et al., 1994) | Laryngeal cancer | Not informative | Information bias (minimal exposure)
(Hansen et al., 1994) | Multiple myeloma | Not informative | Information bias (minimal exposure)
(Harrington and Oakes, 1984) | Sinonasal cancer | Not informative | Selection bias (healthy worker effect)
(Li et al., 2006) | Nasopharyngeal cancer | Not informative | Sensitivity (minimal exposure)
(Li et al., 2006) | Sinonasal cancer | Not informative | Sensitivity (minimal exposure)
(Matanoski, 1989) | Hodgkin lymphoma | Not informative | Selection bias and Information bias
(Mayr et al., 2010) | Sinonasal cancer | Not informative | Confounding
(Solet et al., 1989) | Hodgkin lymphoma | Not informative | Multiple
(Wesseling et al., 1996) | Hodgkin lymphoma | Not informative | Multiple
(Wesseling et al., 1996) | Multiple myeloma | Not informative | Multiple

##### Individual Study Evaluations

Studies that evaluated more than one outcome might be categorized differently for each outcome. The classification of a study could also vary among different analytical groups within a study (e.g., studies of children and adults, with separate analyses for each group), depending on the information presented for the different analyses.

Table B-59 Evaluation of occupational cohort studies of formaldehyde and cancers of the URT (NPC, SN, OHPC) and LHP (HL, MM, LL, ML)

Reference, setting, and design | Participants and selection | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and results | Study sensitivity | Evaluation of major bias categories
Andjelkovich et al. (1995); United States; Cohort study of iron foundry workers working during 1960–1987 with follow-up through 1989. | 3,929 male workers exposed to formaldehyde ≥ 6 mos.; Loss to follow-up 1.3% (1.5% of 2,032 unexposed workers).; Median follow-up ≈15 years.; Average follow-up ≈20.77 years.; All cancer SMR = 0.99. | Individual-level exposure (Yes/No), questionnaire based on industrial hygienist review of detailed work histories; assignments based on job title and industrial hygiene data and information on tasks and plants. Exposure assessment blinded to outcome.; Co-exposed to silica. Possibly co-exposed to polycyclic aromatic hydrocarbons, nickel, and chromium. | Mortality: underlying cause of death based on ICD-8 (Social Security Administration Pension Benefit Information, and National Death Index).; HL: ICD 201.; Higher survival rates for HL could undercount incident cases, but median follow-up is more than 15 years. | Controlled for sex, age, race, and calendar-year specific mortality rates.; Nickel and chromium are associated with URT cancers and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Other co-exposures are not known risk factors for these outcomes. | Exposed vs. unexposed.; SMRs (95% CI).; Latency not evaluated.; No specific estimate of the expected number of NPC or SNC cases was reported, so no SMR was reported for these outcomes. | HL: 1; Larynx: 3; NPC: 0; SNC: 0 | SUMMARY: HL, Larynx, NPC, SNC: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Confounding possible for URT cancers. Low sensitivity (few cases).
Band et al. (1997) Canada; Cohort study of pulp and paper workers, working before 1950 with follow-up through 1982. | 28,200 male workers employed at least one year by January 1950.; Loss to follow-up < 6.5% for workers exposed to the sulfate process (67% of original cohort of 30,157 were exposed to the sulfate process) and loss to follow-up < 20% for workers exposed to the sulfite process.; Average follow-up ≈19.42 years.; All cancer SMP = 1.03. | Hire and termination dates and type of chemical process of pulping (sulfate vs. sulfite). Individual exposure measures not derived. As a profession, workers were likely exposed to formaldehyde.; Formaldehyde is known to be an exposure for pulp and paper mill workers: job-specific exposures range from 0.2 to 1.1 ppm with peaks as high as 50 ppm (Korhonen et al., 2004).; Co-exposed to arsenic, chlorophenols, sulfuric acid mists, and chloroform.; Co-exposures to dioxin or perchloroethylene are also possible (Kauppinen et al., 1997). | Mortality: underlying cause of death obtained from the National Mortality Database based on ICD version in effect at time of death and standardize to ICD-9 version HL: ICD 201 MM: ICD 203.; Higher survival rates for HL could undercount incident cases, but average follow-up is more than 15 years. | All comparisons adjusted for age and sex.; Confounding not evaluated.; Potential confounders for these outcomes include chlorophenols, acid mists, dioxin, and perchloroethylene and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Other co-exposures are not known risk factors for these outcomes. | SMRs (95% CI).; Duration of exposure evaluated.; Latency evaluated as time since first exposure. | HL: 7; Larynx: 12; MM: 12 | SUMMARY: HL, Larynx, MM: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible.
Beane Freeman et al. (2009); (Beane Freeman et al., 2013) United States; Cohort study of workers in 10 plants using or producing formaldehyde, follow-up through 2004.; [underlined: Related studies:] Initial 10 plant cohort follow-up through 1980 Blair et al. (1986); Blair et al. (1987).; Second set of 10 plant follow-ups through 1994 Hauptmann et al. (2003); Hauptmann et al. (2004a).; Reanalysis of 1 plant Marsh et al. (2002); Marsh et al. (2007).; Reanalysis of Beane Freeman et al. (2009) by Checkoway et al. (2015). | 25,619 workers (12% female) followed from plant start-up or first employment.; Deaths were identified from the National Death Index with remainder assumed to be living. Vital status was obtained for 97.4%.; Median follow-up 42 years.; Average follow-up ≈38.96 years.; All cancer SMR = 0.93. | Individual-level exposure estimates based on job titles, tasks, visits to plants by study industrial hygienists who took 2,000 air samples from representative jobs, and plant monitoring data from 1960 through 1980.; Blinded to outcome.; Median cumulative exposure was 0.6 ppmyears (range = 0.0– 107.4 ppm-years).; Co-exposed to antioxidants, benzene, carbon black, dyes and pigments, melamine, hexamethylenetetramine, phenols, plasticizers, urea, wood dust.; (Beane Freeman et al., 2013) sampled cohort members and found no association between smoking and formaldehyde. Blair et al. (1986) noted that smoking habits among this cohort did not differ substantially from those of the general population.; Checkoway et al. (2015) redefined peak exposures as the referent category for any exposures <2 ppm of hourly, daily, weekly or monthly frequency as well as exposures > 2 ppm if they occurred hourly or monthly. | Mortality: underlying cause from death certificates, ICD-8.; HL: ICD 201; MM: ICD 203; LL: ICD 204 ML: ICD 205.; Larynx: ICD 161; NPC: ICD 147; SNC: ICD 160.; Higher survival rates for HL and LL could undercount incident cases, but median follow-up is more than 42 years.; Checkoway et al. (2015); AML: 205.0; CML: 205.1 | All comparisons adjusted for calendar year, age, sex, and race.; Internal analysis adjusted for pay category.; For HL, MM, LL, ML: Benzene is a potential confounder but was controlled for.; For NPC, SN: Wood dust is a potential confounder but was controlled for.; Eleven co-exposures examined as potential confounders, but none were found to be confounders. | Internal: Poisson regression; RR (95% CI) by exposure categories (4 levels), for peak, average, cumulative exposures.; Latency was evaluated.; External: SMRs (95% CI).; Checkoway et al. (2015); Cox PH regression; HR (95% CI) by exposure categories (4 levels collapsed to 3 by widening the ref. cat. due to small numbers).; Latency was evaluated. | HL: 27; MM: 59; LL: 37; ML: 48; Larynx: 48; NPC: 11; SNC: 5; Checkoway et al. (2015) AML: 34; CML: 13 | SUMMARY: SNC: MEDIUM(No appreciable bias); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A); Low sensitivity (few cases); HL, Larynx, LL, ML, MM, NPC: HIGH (No appreciable bias); Checkoway et al. (2015); SUMMARY: ML, AML, CML: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D due to reclassification of peak exposures as unexposed) with attenuation of association.
Bertazzi et al. (1986). Italy; Cohort study of Italian chemical workers in plant producing formaldehyde resins. | 1,332 male workers ever employed in the plant between 1959 and 1980.; Deaths were identified from vital statistics offices. Vital status was 98.6% complete.; Average follow-up ≈15.26 years.; All cancer SMR = 1.54. | Individual-level exposure estimates based on occupational histories from the personnel office with supplement information from 350 employed workers alive at the end of follow-up in 1980.; 5,731/20,366 (28%) person years were considered to be exposed to formaldehyde.; Other exposures included styrene, xylene, toluene, and methyl isobutyl ketone. | Death certificates used to determine cause of deaths from nasal cancer (ICD-8). | Controlled for age, sex and calendar time.; Styrene is associated with LHP cancers but not URT cancers.; Other co-exposures are not known risk factors for this outcome. | SMRs (95% CI).; Latency evaluated. | SNC: 0 cases | SUMMARY: SNC: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group B) with attenuation of association. Low sensitivity (few cases).
Boffetta et al. (1989). United States; Nested matched case control of MM within general population cohort. Baseline enrollment in 1982 with bi-annual follow-up in 1984 and 1986. | 508,637 men and 676,613 women (57%) in American Cancer Society’s Cancer Prevention Study II, with sufficient data on occupation.; Loss to follow-up 1.5%. Death certificates for 84% of deceased subjects.; Four controls per case were matched for age, sex, ethnic group, and residence. | Self-report from baseline questionnaire occupational history, based on specific question about exposure to formaldehyde (Ever/Never).; Other exposures included asbestos, chemicals, acids, solvents, coal or stone dusts, coal tar, pitch, asphalt, diesel and gasoline exhausts, dyes, pesticides, herbicides, textile fibers/dusts, wood dust, X-rays, and radioactive material. | Mortality: underlying or contributing cause from death certificates MM: ICD-9: 203.; Analysis limited to “incident” cases (i.e., had not indicated a history of cancer in baseline questionnaire). | Matching controlled for sex, age, ethnic group, residence, smoking, education, diabetes, X-ray treatment, farming, pesticide, and herbicide exposure.; Other co-exposures were not associated with LHP cancers. | Mantel-Haenszel matched OR (95% CI).; Latency not evaluated. | MM: 128 (4 exposed) | SUMMARY: LOW ↓(Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Low sensitivity (few exposed cases).
Coggon et al. (2003); Coggon et al. (2014) Great Britain; Cohort study of British chemical workers in factories using or producing formaldehyde, working before 1940 with follow-up through 2012.; [underlined: Related studies:] Initial follow-up through 1981 Acheson et al. (1984b).; Second follow-up through 1989 Gardner et al. (1993).; Third follow-up through 2000: Coggon et al. (2003). | 14,008 men in six chemical facilities. Cohort mortality followed from 1941 until December 2012. Vital status was 92% complete.; Cause of deaths was known for 99% of 5,185 deaths through 2000. This figure was not provided on 7,378 deaths through 2012.; All cancer SMR = 1.10. | Individual level categorical exposure assessment based on employment records evaluated occupational hygienist who classified job titles according to their exposure to formaldehyde based on measurement made after 1970 and workers’ recall of irritant symptoms prior to 1970. Background exposure corresponded to <0.1 parts per million (ppm), low exposure to 0.1–0.5 ppm, moderate exposure to 0.6–2.0 ppm, and high exposure to >2.0 ppm.; Blinded to outcome.; Each worker assigned the highest level of exposure ever experienced (i.e., “ever highly exposed”). Subjects’ assigned exposure grade may exceed average workplace exposure.; Potential low-level exposure to styrene, ethylene oxide, epichlorohydrin, solvents, asbestos, chromium salts, and cadmium. | Mortality: underlying cause from death certificates, ICD-9.; HL: ICD 201; ML: ICD 205; MM: ICD 203.; Larynx: ICD 161; MM: ICD 203; NPC: ICD 147; OHPC: ICD 146-149 minus 147; SNC: ICD 160.; Note than HL follow-up was through 2000 Coggon et al. (2003).; Higher survival rates for HL and LL could undercount incident cases, but follow-up is more than 50 years. | Adjusted for calendar year, age.; Styrene is associated with LHP cancers but not URT cancers.; Asbestos is associated with URT cancers, including laryngeal cancer.; Authors stated that the extent of co-exposures was expected to be low. Potential for confounding may be mitigated by low co-exposures. | SMRs (95% CI) by low/moderate and high exposure categories.; Latency not evaluated. | NPC: 1; SNC: 2; OHPC: 16; Larynx: 22; HL: 15; MM: 28; ML: 36; Note that HL results is from 2003. | SUMMARY: NPC, SNC: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases).; HL, Larynx, ML, MM, OHPC: MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association.
Coggon et al. (2014) Great Britain; Nested case-control study.; [underlined: Related studies:] Initial follow-up through 1981 Acheson et al. (1984a).; Second follow-up through 1989 Gardner et al. (1993).; Third follow-up through 2000 Coggon et al. (2003). | Internal comparison using nested case-control study within cohort with 10 controls per case individually matched by facility, mortality status and age within 2 years. | Individual level categorical exposure assessment based on employment records evaluated occupational hygienist who classified job titles according to their exposure to formaldehyde based on measurement made after 1970 and workers’ recall of irritant symptoms prior to 1970. Background exposure corresponded to <0.1 ppm, low exposure to 0.1–0.5 ppm, moderate exposure to 0.6–2.0 ppm, and high exposure to >2.0 ppm.; Blinded to outcome.; Each worker assigned the highest level of exposure ever experienced (i.e., “ever highly exposed”). Subjects’ assigned exposure grade may exceed average workplace exposure.; Potential co-exposure to styrene and solvents. | Incidence or morality: cancer registries and death certificates, ICD-code in effect at time of diagnosis or death. Cases were either incident diagnoses, underlying cause of death, or contributing cause of death.; Larynx: 161; MM: ICD 203; NPC: ICD 147; OHPC: ICD 146-149 minus NPC; SN: ICD 160. | Matched analysis controlled for facility and age.; Styrene is associated with LHP cancers but not URT cancers.; Authors stated that the extent of co-exposures was expected to be low.; Potential for confounding may be mitigated by low extent of co-exposures. | ORs (95% CI) by low, moderate, high exposure for less than 1 year, and high exposure for 1 year or more.; Latency only evaluated by exposure duration and category at 5 years prior to diagnosis or death for each matched set. | Larynx: 53; Pharynx: 28; OHPC: 27; ML: 45; MM: 28 | SUMMARY: Larynx, ML, MM, OHPC: MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association.
Dell and Teta (1995) United States; Cohort study of workers in a plastics manufacturing and research and development facility which made phenol-formaldehyde resins, working 1946–1967 with follow-up through 1988. | 5,932 white men employed for at least 7 mos.; Vital status was 94% complete. Death certificates obtained for 98%.; Average follow-up 32 years.; All cancer SMR = 1.02. | Individual exposure measures not evaluated. Only 111 men (2%) had work assignments involving formaldehyde. However, as the plant manufactured and used formaldehyde since 1931, a larger percentage may have actually been exposed.; Variation in presumed exposure by department and pay status.; Co-exposures: acrylonitrile, asbestos, benzene, carbon black, epichlorohydrin, PVC (vinyl chloride), styrene, and toluene. | Mortality: underlying cause from death certificates, ICD version in effect at time of death.; MM: ICD 203. | Adjusted for sex, race, age, and calendar-year.; Asbestos is not associated with LHP cancers.; Benzene and styrene were not evaluated as potential confounders and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect. | SMRs (95% CI) by major department.; Latency evaluated with exposure lag times of 10 and 15 years. | MM: 8; NPC: 0 | SUMMARY for MM: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible.; SUMMARY for NPC: Not informative Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Confounding possible. Low sensitivity (few cases).
Edling et al. (1987b) Sweden; Cohort study of workers in a production plant making abrasives bound with formaldehyde resins, working 1955 to 1981 with follow-up through 1983. | 521 male workers employed at least 5 years.; Vital status was 97% complete.; All cancer SMR = 0.93. | Whole cohort assumed to be exposed with some individual’s exposed to high peak exposures.; Manufacture of grinding wheels bound by formaldehyde resins exposed company workers to 0.1–1 mg/m^3^formaldehyde.; 59 workers (11%) had intermittent heavy exposures to formaldehyde with peaks up to 20–30 mg/m^3^.; Co-exposed to aluminum oxide and silicon carbide. | Incidence (ICD-8), from National Cancer Registry.; MM: ICD-203. | Controlled for sex, age, and calendaryear-specific mortality rates.; Co-exposures are not known risk factors for this outcomes. | SIRs (95% CI).; Latency not evaluated. | MM: 2 | SUMMARY: MM: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases).
Fryzek et al. (2005) United States; Cohort mortality study of workers in motion picture film processing, working 1960 to 2000, with follow-up through 2000. | 2,646 workers (11% female) employed at least 3 mos.; 178 workers (7%) excluded for missing work histories or work outside the study period.; Vital status obtained for 99.7%; cause of death data for 655 of 666 decedents (98.3%).; Average length of follow-up ≈20.58 years.; All cancer SMR = 1.1. | Individual-level occupational histories were used to classify workers in job families matched to past industrial hygiene surveys conducted in house and by state program.; Formaldehyde used in “film developing” and possibly in ‘maintenance’. Personal and area sample averaged 0.28–0.29 ppm with range 0.06– 0.52.; Co-exposures included methanol, methyl chloroform, perchloroethylene, and hydroquinone. | Mortality: underlying cause from death certificates.; HL: ICD-9 201; MM: ICD-9 203.; Higher survival rates for HL could undercount incident cases, but average follow-up is more than 20 years. | Controlled for age, sex, race, and time period.; Perchloroethylene may be a risk factor for multiple myeloma as may hydroquinone which is a metabolite of benzene, a known cause of LHP cancers.; Potential for confounding is unknown but could have substantially inflated the observed effect due to the high correlation of these exposures with formaldehyde. | SMRs (95% CI).; Decade of exposure, duration of exposure and time since first exposure were evaluated.; Latency was evaluated as time since first exposure. | HL: 0; MM: 2 | SUMMARY: NOT INFORMATIVE Critical limitation: Confounding
Hall et al. (1991) Great Britain; Cohort study of British pathologists.; [underlined: Related studies:] Initial follow-up through 1973 Harrington and Shannon (1975); Second follow-up through 1980 Harrington and Oakes (1984). | 4,512 pathologists from the Royal College of Pathologists and the Pathological Society of Great Britain from 1974–1987.; Deaths among those >85 years were censored. Vital status was obtained from the census, a national health registry, and other sources (100%). Cause of death data for 222 of 231 individuals (96.5%).; All cancer SMR = 0.44. | As a profession, pathologists were highly exposed to formaldehyde as a main ingredient in tissue fixative.; NIOSH (Industry Selection for Determination of Extent of Exposure, 1979) has reported mean formaldehyde concentrations of 4.35 ppm with range (2.2– 7.9).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: cause of death = Hodgkin lymphoma, ICD 8: code 201.; Higher survival rates for HL could undercount incident cases, but maximum follow-up is 13 years with 5% mortality during follow-up. | Controlled for age, sex, and calendar year.; Chemical co-exposures are not known risk factors for this outcome.; Radiation exposure likely to be poorly correlated with formaldehyde. | SMRs (95% CI) developed from the English and Welsh populations.; Latency not evaluated. | HL: 1; Low power due to the rarity of cases. | SUMMARY: NOT INFORMATIVE Critical limitations: Selection bias and information bias.
Hansen et al. (1994) Denmark; Cohort study of workers at a Danish pharmaceutical plant. | 10,889 employees (51% women) ever employed 1964–1988 at a pharmaceutical plant. Cases were extracted from the Danish Cancer Registry.; All cancer SIR (men)=0.95 All cancer SIR (women) = 1.16. | No individual-level exposures estimated: whole cohort assumed to be exposed.; Formaldehyde was one of many exposures in this industry but [underlined: not] a main ingredient or product.; Co-exposures may have included asbestos, antibiotics, chloroform, dichloromethane, enzymes, ethylene oxide, glucagon heparin, insulin, silica, sex hormones, sodium saccharin, and synthetic agents. | Incidence: cases from Danish Cancer Registry classified according to ICD-7.; HL: ICD 201; MM: ICD 203.; Higher survival rates for HL could undercount incident cases, although average follow-up is 13 years. | Controlled for age, sex, and calendar year.; Asbestos is associated with URT cancers. Ethylene oxide is associated with LHP cancers. Neither were evaluated as potential confounders.; Potential for confounding is mitigated by low formaldehyde exposure and likely low correlation with asbestos and ethylene oxide. | SIRs (95% CI).; Latency not evaluated. | HL: 4; Larynx: 5; MM: 0; Low power due to the rarity of cases and low confidence in formaldehyde exposure. | SUMMARY: NOT INFORMATIVE Critical limitation: Information bias (minimal exposure)
Hansen and Olsen (1995). Denmark; Cohort study of Danish men, URT cancers diagnosed 1970–1984. | 2,041 men with incident cancer whose longest work experience occurred at least 10 years before cancer diagnosis.; Cases matched with employment records from pension fund (72%) with remainder being self-employed, pensioners, & unemployed. External comparison with general population.; Average follow-up ≈13 years. | Individual occupational histories including industry and job title established through company tax records.; Considered exposed if worked in plant with more than 1 kg formaldehyde used per employee per year. Very crude exposure assessment.; No information on co-exposures except for wood dust. | Incident cases identified in Danish Cancer Registry (ICD-7).; NPC: 146; SNC: 160; Larynx: 161; HL: 201.; Higher survival rates for HL could undercount incident cases, although average follow-up is approximately 13 years. | Controlled for age, sex, and calendar time.; Sinonasal cancer risk was evaluated controlling for wood dust.; While other co-exposures were not evaluated, the overall correlation between co-exposures in multiple occupational industries is likely to be low. | SPIRs (95% CI) (Standardized proportionate incidence ratio) - proportion of cases for a given cancer in formaldehyde-associated companies relative to the proportion of cases for the same cancer among all employees in Denmark.; Latency addressed by inclusion criteria. | NPC: 4; SNC: 13; Larynx: 32; HL: 12 | SUMMARY: HL, Larynx, NPC, SNC: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity for NPC (few cases).
Harrington and Oakes (1984). Great Britain; Second cohort study of British pathologists.; [underlined: Related studies:] Initial follow-up through 1973 Harrington and Shannon (1975); Third follow-up through 1987 Hall et al. (1991). | 2,720 pathologists from the Royal College of Pathologists and the Pathological Society of Great Britain from 1974–1980.; Deaths among those >85 years were censored. Vital status was obtained from the census, a national health registry, and other sources (100%). 96% of death certificates were obtained with 91 reporting a cause of death.; All cancer SMR = 0.61. | As a profession, pathologists were highly exposed to formaldehyde as a main ingredient in tissue fixative.; NIOSH (Industry Selection for Determination of Extent of Exposure, 1979) has reported mean formaldehyde concentrations of 4.35 ppm with range (2.2– 7.9).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: cause of death sinonasal cancer. | Controlled for age, sex, and calendar year.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | SMRs (95% CI) developed from the English and Welsh populations.; Latency not evaluated. | SNC: 0; Low power due to the rarity of cases. | SUMMARY: NOT INFORMATIVE Critical limitations: Selection bias and information bias.
Hauptmann et al. (2009). United States; Nested case-control study within extension of embalmers cohorts described in Walrath and Fraumeni (1983, 1984); Hayes et al. (1990). | Embalmers (8% women) from national and state funeral directors associations and licensing boards. Died 1960–1986. Participation rate of case interviews was 220/228 (96%) and 265/282 eligible controls (94%). Controls randomly selected from individuals in the funeral industry whose deaths were attributed to other causes. Controls stratified to be similar to data source, sex, and dates of birth and death (5-year intervals). | Individual level, based on lifetime work practices and exposures to formaldehyde obtained by interview with next of kin or coworkers (96% of cases and controls) with information on occupational exposure resulting from embalming.; Interviewers blinded to outcome.; Exposure levels assigned based on laboratory reconstruction of exposures for specific work practices.; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: underlying cause from death certificates, ICD-8.; MM: ICD 203; LL: ICD 204; ML: ICD 205.; Higher survival rates for HL could undercount incident cases, but average follow-up is more than 39 years (485 cases and controls/19,104 person-years). | Controlled for date of birth, age at death, sex, data source, and smoking.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | Logistic regression, OR (95% CI) by exposure categories (4 levels) for duration, number of embalmings, cumulative exposure, average intensity, timeweighted average, and peak exposure measures.; Analyses of duration of exposure for ML is proxy for latency.; Latency not evaluated for MM or LL. | ML: 34 (17 acute); MM: n cases not reported but must be greater than 5 due to size of se(ln(OR)).; LL: 99; NPC: 4 | SUMMARY: ML: HIGH (No appreciable bias); LL, MM: MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.; NPC: MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A) Low sensitivity (few cases).
Hayes et al. (1990) United States; Cohort study of embalmers.; [underlined: Related study:] Hauptmann et al. (2009) | 4,046 deceased male embalmers and funeral directors, derived from state licensing boards and funeral director who died during 1975–1985 and a death certificate could be obtained.; Death certificates obtained for 79% of potential study subjects.; The 21% missing death certificates considered to missing at random because all embalmers were considered to be exposed to formaldehyde.; All cancer PMR (white) = 1.07 (nonwhite) = 1.08. | Individual exposure measures not derived. Occupation confirmed from death certificates.; Separate study estimated personal formaldehyde exposures from 0.98 ppm (high ventilation) to 3.99 ppm (low ventilation), with peaks up to 20 ppm.; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: underlying cause of death from death certificates,; ICD-8;; ICD 201 = HL; ICD 203 = MM; ICD 204 = LL; ICD 205 = ML.; Higher survival rates for HL and LL could undercount incident cases, and median follow-up is unknown. | Controlled for calendar year, age, sex, and race.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | PMR (95% CI).; Latency not evaluated. | HL: 3; Larynx: 7; LL: 7; ML: 24; MM: 20; NPC: 4; SNC: 0; Possible undercounting of cases due to abbreviated death certificate search. | SUMMARY: Larynx, LL, ML, MM: MEDIUM ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association.; HL, NPC, SNC: LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases).
Jakobsson et al. (1997); Sweden; Cohort study of workers grinding stainless steel. | 727 male employees of 2 plants producing stainless steel sinks and sauce pans employed at least 1 year during 1927– 1981 with minimum 15-year follow-up.; Of 823 original workers, 23 (3%) could not be identified, 12 died or emigrated before 1952 (1%), and 61 did not exceed the 15 year waiting period. No further losses to follow-up.; All cancer SIR = 0.9. | No individual exposure measures.; Presumed exposure was to phenol-formaldehyde resins on ribbons or plates in grinding workers.; Co-exposures may have included chromium, nickel, and abrasive dusts including silicon carbide, aluminum oxide, silicon dioxide, and clay.; No wood dust exposures. | Incidence: cases from Swedish Tumor Registry SN ICD-7 160. | Adjusted for sex, age, and calendar year.; Nickel and chromium are associated with URT cancers and would likely be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Other co-exposures are not known risk factors for these outcomes. | SIRs (95% CIs).; Latency addressed by enforcing a 15-year waiting period to begin observation. | Larynx:1; SNC: 0; Low power due to the rarity of cases. | SUMMARY: Larynx, SNC: LOW ↓ (Potential bias toward the null); High potential for information bias with attenuation of association (Exposure Group D). Confounding possible. Low sensitivity (few cases).
Levine et al. (1984a) Canada; Cohort study of undertakers. | 1,477 male undertakers first licensed during 1928– 1977 with mortality follow-up from 1950–1977.; Vital status was 96% complete with cause of death available for 94%.; Average follow-up 25 years.; All cancer SMR = 0.87. | As a profession, undertakers/embalmer s were highly exposed to formaldehyde as a main ingredient in tissue fixative.; Kerfoot and Mooney (1975) reported mean formaldehyde concentrations for embalmers in funeral homes of 0.74 ppm with range (0.09–5.26).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: underlying cause from death certificates (ICD-8). Nose, middle ear, sinuses: 160 Larynx: 161. | Controlled for calendar year, age, and sex.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | SMR, 95% CI.; Latency was not evaluated for these endpoints. | SNC: 0; Larynx: 1; Low power due to the rarity of cases. | SUMMARY: Larynx, SNC: LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases).
Li et al. (2006) China; Nested case-cohort study within a cohort study of textile workers. | 67 women diagnosed during 1989– 1998 with nasopharyngea l cancers were identified in a cohort of 267,400 female textile workers born during 1925–1958.; Nine additional cases (12% of total) were excluded due to lack of occupational histories.; 3,188 controls randomly selected from the cohort; frequency matched by age. | Individual level, based on job exposure matrix developed for this industry/setting (unclear extent of industrial hygiene specifically for formaldehyde).; No historical measurements of exposures. No cases were classified as exposed and only 10/3,188 controls (0.3%) were classified as exposed.; EPA considered the potential for formaldehyde exposure to be exceedingly low.; Co-exposed to cotton dust. | Incidence or mortality. Diagnosis of nasopharyngeal cancer or sinonasal cancer reported to a cancer and death registry operated by the Shanghai Textile Industry Bureau.; NPC: ICD-9 147; SN: ICD-9 160. | Controlled for age and sex.; Dusts could be a potential confounder but due to the rarity of formaldehyde exposure the correlation would be minimal. | Cox proportiona hazards modelin adapted for case cohort design. Hazard ratios (9CI).; Duration and latency were not evaluated. | NPC: 10; No cases exposed.; Very low power due to the rarity of exposure. | SUMMARY: NOT INFORMATIVE Critical limitation: Very low sensitivity rare exposure.
Malker et al. (1990) Sweden; Cancer registry-based study, NPC diagnosed 1961–1979. | 471 employed men with incident NPC cancer. | No individual exposure measures.; Occupations and industries with potential exposure to formaldehyde: bookbinders, fiberboard makers, textile workers, furniture makers, chemical workers, physicians, foundry workers, biologists, tanners, and skin processors, worker employed in veneer and plywood plants and in sugar processing plants.; Co-exposure information not provided. | Incident cases identified in Swedish Cancer-Environment Registry.; Microscopic confirmation obtained for 99.6% of NPC cases. 48% squamous cell carcinomas, 37% unspecified carcinomas, 5% transitional cell carcinomas, and 3% adenocarcinomas. | Controlled for age and region.; Variation in exposure was not evaluated.; Co-exposures were also not evaluated.; Fiberboard workers are also exposed to wood dust.; Wood dust is associated with URT cancers and would likely be positively correlated with formaldehyde exposure. Potential for confounding is unknown but could have inflated the observed effect. | SIRs (95% CI).; Latency not evaluated. | NPC: 4 cases in workers exposed in fiberboard plants | SUMMARY: NPC: Low ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (few exposed cases).
Marsh et al. (2002); Marsh et al. (2007) United States; Nested case-control study within a cohort study of workers in one plant using formaldehyde.; [underlined: Related studies:] Initial 10 plant cohort follow-up through 1980 Blair et al. (1986); Blair et al. (1987).; Second set of 10 plant follow-ups through 1994 Hauptmann et al. (2003); Hauptmann et al. (2004a).; Third set of 10 plant follow-ups through 2004 Beane Freeman et al. (2009); Beane Freeman et al. (2013). | 7,328 workers employed at a formaldehyde using plant in Connecticut followed from 1945 through 1998.; Vital status was identified from the National Death Index, private businesses, or state and local agencies, and was 98.4% complete; cause of death data for 95% of 2,872 deaths.; Average follow-up ≈32.89 years.; All cancer SMR = 1.08. | Worker-specific exposure measures from job exposure matrix based on available sporadic plant monitoring data from 1965–1987, job descriptions, and verbal job descriptions by plant personnel and industrial hygienists.; Exposure assessment did not include the same industrial hygiene sampling conducted by Stewart et al. (1986) used in the Beane Freeman et al. (2009); Beane Freeman et al. (2013) analyses which included this plant.; Exposure estimates were on average 10 times lower than those of other studies in this plant (Blair et al., 1986; Beane Freeman et al., 2009; Beane Freeman et al., 2013).; From Beane Freeman et al. (2009); Beane Freeman et al. (2013): Co-exposed to antioxidants, benzene, carbon black, dyes and pigments, melamine, hexamethylenetetramin e, phenols, plasticizers, urea, wood dust. | Mortality: oropharyngeal code ICD-9: 146. Hypopharyngeal code ICD-9: 148. Nasopharyngeal code ICD-9: 147. Pharyngeal ICD-9: 146–149.; Death certificates used to determine underlying cause of death according to the ICD codes at time of death. Histological typing not reported. | Controlled for age, race, sex, and time period.; Comparison was with U.S. death rates and with death rates in 2 counties.; Benzene is not associated with URT cancers. Potential confounders were evaluated but only smoking was found to be a potential confounder and was controlled for.; Co-exposures to pigments and particles were evaluated and were found not to be confounding. Marsh et al. (2002) attempted to evaluate smoking but data were incomplete. No other potential confounders were evaluated.; Beane Freeman et al. (2009); Beane Freeman et al. (2013) evaluated 11 potential confounders among a set of 10 plants that included this one and did not find any confounding. | SMR (95%CI) Secondary analysis for NPC.; EPA derived SMRs for the combination of oropharyngeal, hypopharyngeal and unspecified pharyngeal cancer by NPC cases from all pharyngeal cancers.; Latency not evaluated. | Oro: 5; Hypo: 3; Low power due to the rarity of cases.; NPC: cases included in Beane Freeman et al. (2013). | SUMMARY: Oro- alone & Hypo-alone: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association. Low sensitivity (few cases).; OHPC together: MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association.
Matanoski (1989) United States; Prospective mortality cohort study with two external comparison groups. | 3,644 deceased male pathologists, derived from membership rolls of multiple professional societies.; Mortality followed through 1978. Death certificates obtained for 94% of potential study subjects, 3% from obituary notices and 3% presumed dead.; All cancer SMR = 0.78. | As a profession, pathologists were highly exposed to formaldehyde as a main ingredient in tissue fixative.; NIOSH (Industry Selection for Determination of Extent of Exposure, 1979) has reported mean formaldehyde concentrations of 4.35 ppm with range (2.2– 7.9).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: death certificates and obituary notices used to determine cause of death from Hodgkin lymphoma (ICD-8: 201).; Higher survival rates for HL could undercount incident cases, although median follow-up is probably more than 15 years since follow-up was from the early 20^th^ century through 1978. | Controlled for sex, race, age, and calendar-year-expected deaths from the U.S. population and psychiatrists.; Variation in exposure was not evaluated.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | SMRs (95% CI).; Latency not evaluated. | HL: 2 cases total; Low power due to the rarity of cases. | SUMMARY: NOT INFORMATIVE Critical limitation: Selection and information biases.
Meyers et al. (2013) United States; Prospective cohort mortality study.; [underlined: Related studies:] Initial cohort follow-up Stayner et al. (1988),; Second follow-up Pinkerton et al. (2004) | Workers in 3 U.S. garment plants (n=11,043) in Georgia and Pennsylvania exposed for at least 3 mos (82% female). Vital status was followed through 2008 with 99% completion. Causes of death were obtained for 3,904 (99.7%) of the 3,915 identified deaths.; Average follow-up ≈37.52 years.; All cancer SMR = 0.96. | Individual-level exposure estimates for 549 randomly selected workers during 1981 and 1984 with 12–73 within each department. Formaldehyde levels across all departments and facilities were similar.; Exposures ranged from 0.09–0.20 ppm. Overall geometric mean concentration of formaldehyde was 0.15 ppm, (GSD 1.90 ppm). Area measures showed constant levels without peaks.; No other chemical exposures were identified by the industrial hygiene surveys.; There was no information on smoking in this analysis, however, according to Stayner et al. (1988), “the overall prevalence of cigarette smokers was 29.4%. In plant 1 the prevalence was 26.6%, in plant 2 it was 33.5%, and in plant 3 it was 29.4%. These figures are similar to those reported in a 1980 survey of adult Americans, in which 29.2% of females and 38.3% of males over the age of 20 were current cigarette smokers [NCHS, 1985].” | Mortality: death certificates used to determine the underlying cause of death (ICD-10):; NPC: C11; OHPC: C09-C10, C12-C14; SN: C30-31; Larynx: C32.; HL:C81; LL: C91.0-91.3, C91.5-91.9; ML: C92; MM: C88.7, 88.9, 90.; Higher survival rates for HL could undercount incident cases, but average follow-up is more than 37 years Histological typing not reported. | Adjusted for sex, age, race, and calendar-year specific US mortality rates.; No other chemical exposures were identified by the industrial hygiene surveys that could influence the findings. | SMRs (95% CI), by exposure categories (3 levels) for duration, time since first exposure measures.; SRRs (95% CI) (internal comparison categories of duration of exposure.; Latency effects were examined for leukemia only. | NPC: 0; OHPC: 6; SNC: 0; Larynx: 4; ML; 21 (14 acute; 5 chronic); LL: 6; HL: 4; MM: 23 | SUMMARY: LL, ML: HIGH (No appreciable bias); Larynx, NPC, SNC: LOW ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases).; HL, MM, OHPC: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association.
Ott et al. (1989) United States (West Virginia); Nested case-control study within two chemical manufacturing plants. | 29,139 male workers followed from 1940–1978. Loss to follow-up 3.6%. 95.4% of death certificates obtained.; Frequency matching of controls (5:1) from the total employee cohort according to a group-matched incidence density sampling design. | Individual-level exposure classification based on company records of work assignments linked to records on department usage of formaldehyde. Exposures during 1940 to 1978.; 21 different chemicals were evaluated including benzene with much cross exposure. | Mortality: underlying cause from death certificates, ICD version in effect at time of death.; Higher survival rates for LL could undercount incident cases, but average follow-up is likely more than 15 years as follow up was initiated in 1940 and ceased in 1978. | Unconditional logistic regression. Controlled for sex and age.; Controlling for age did not change results.; Benzene was not evaluated as a potential confounder and may be positively correlated with formaldehyde exposure.; Potential for confounding is unknown but could have inflated the observed effect.; Potential for confounding may be mitigated by rarity of co-exposures among cases. | OR (95% CI).; Analyses conducted with a 5-year exposure lag. Limited adjustment for latency. | MM: 20; ML: 39; LL: 18; ≤2 exposed cases for each endpoint; Low power due to the rarity of exposure. | SUMMARY: LL, ML, MM: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association. Confounding possible. Low sensitivity due to rarity of exposure.
Pira et al. (2014) Italy; Prospective cohort mortality study with external comparison group. | 2,750 workers employed at a laminated plastic factory in Italy for at least 180 days between 1947 and 2011 followed until May 2011. Deaths were identified from population registries. Vital status was 96.9% complete and only 3.1% lost to follow-up. | Formaldehyde is a byproduct from the resins used in production process and all workers were presumed to have been exposed.; Exposure period from 1947 through 2011. Median length of follow-up: 23.6 years. Duration and timing since first exposure were not evaluated. | Death certificates used to determine UCOD from multiple myeloma (ICD-9: 203). | Adjusted for sex, age, and 5-year calendar periods using mortality rates from the Piedmont region.; Co-Exposures not evaluated. | SMRs (95% CI).; Latency not evaluated. | MM: 0 cases | SUMMARY: MM: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (few cases).
Robinson et al. (1987); United States; Prospective cohort mortality study. | Plywood mill workers (n = 2,283) employed at least 1 year during 1945–1955 followed for mortality until 1977 with vital status for 98% and death certificates for 97% of deceased.; Average follow-up ≈25.22 years.; All cancer SMR = 0.7. | Individual exposure measures not derived.; Presumed exposure to formaldehyde-based glues used to manufacture and patch plywood.; Co-exposure to carbon disulfide, pentachlorophenol, wood dust. | Mortality: underlying cause from death certificates (ICD-7) HL: 201 MM: 203.; Higher survival rates for HL could undercount incident cases, but average follow-up is more than 25 years. | Adjusted for sex, age, race, and calendar-year-specific U.S. mortality rates.; Some exposed workers also exposed to pentachlorophenol for more than 1 year.; EPA concluded that pentachlorophenol is likely to be carcinogenic based on strong evidence from epidemiologic studies of increased risk of MM.; Potential for confounding is unknown but could have inflated the observed effect for MM but not for HL. | SMRs (90% CI).; Latency not evaluated. | MM: 3 cases HL: 2 cases (2 cases, whole cohort of mill workers; 2 cases, subcohort of exposed workers) | SUMMARY: MM: Not informative, Critical limitations: Selection bias, information bias, confounding.; HL: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Low sensitivity (few cases).
Saberi Hosnijeh et al. (2013) Europe; Prospective cohort study. | 241,465 men and women recruited from 10 European countries during 1992–2000. Participants were predominantly ages 35–70 at recruitment and were followed up through 2010. | Occupational histories obtained by questionnaire about ever working in any of 52 occupations considered to be at high risk of developing cancer. Occupational exposures estimated as “high,” “low,” and no exposure by linking to a JEM. | Incident primary leukemias identified from cancer registries, health insurance records, pathology registries and contact with subjects of their next of kin. | Controlled for age, sex, smoking, alcohol, physical activity, education, BMI, family history of cancer, country, other occupational exposures, and radiation. | Proportional hazards regression; HRs (95% CI).; Latency was not evaluated. | LL: 67/225 exposed; ML: 49/179 exposed | SUMMARY: LL, ML: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association.
Siew et al. (2012) Finland; National cohort study. | All Finnish men born during 1906–1945 who participated in census and were employed in 1970 (n=1.2 million). Cancer cases identified by national registry during 1971–1995. | Occupational history from census records were linked to the national JEM to code each cohort member with “any” exposure to formaldehyde or “none.” Only some use of “industry” information.; 3% of NPC cases exposed; 5% of SNC cases exposed; Co-exposure wood dust was collected. | Diagnosis of cancer reported to the Finnish Cancer Registry. | Controlled for age, sex, socioeconomic status, smoking, and wood dust. | SIRs (95% CI).; A 20-year latency period was assumed. | NPC: 149; SNC: 167.; Baseline incidence of NPC in this population is the lowest in the world. | SUMMARY: NPC, SNC: LOW ↓(Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity (low background rate of cancer).
Solet et al. (1989) United States; Proportionate mortality study of pulp and paper workers. | 201 white male pulp and paper producing workers who died during 1970–1984 and had at least 10 years of experience in the industry.; All cancer PMR = 1.31. | Occupational history from union records identified workers in the pulp and paper producing jobs.; Formaldehyde is known to be an exposure for pulp and paper mill workers: job-specific exposures range from 0.2 to 1.1 ppm with peaks as high as 50 ppm (Korhonen et al., 2004).; From Band et al. (1997), co-exposed to arsenic, chlorophenols, sulfuric acid mists, and chloroform.; According to a review Kauppinen et al. (1997) co-exposures to dioxin or perchloroethylene are also possible. | Mortality: underlying cause from death certificate submitted to the Union Pension Fund.; HL: ICD-8 201.; Higher survival rates for HL could undercount incident cases, but average follow-up is probably more than 15 years because workers had to have at least 10 years of experience in the industry. | Controlled for age, sex, race, age at death, and calendar time.; Confounding not evaluated.; Potential confounders for these outcomes include chlorophenols, acids mists, dioxin, and perchloroethylene, which are likely to have been positively correlated with formaldehyde exposure.; Other co-exposures are not known risk factors for these outcomes.; Potential for confounding is unknown but could have inflated the observed effect. | PMRs (95% CI).; Latency not evaluated. | HL: 1 case; Low power due to the rarity of cases. | SUMMARY: NOT INFORMATIVE Critical limitation: (Information bias and sensitivity)
Stellman et al. (1998) United States; General population cohort. Baseline enrollment in 1982; follow-up through 1988. | 317,424 men enrolled in the American Cancer Society’s Cancer Prevention Study II in 1982. Follow-Up was 98% complete.; Median follow-up 6 years.; Average follow-up ≈5.79 years. | Individual level, based on questionnaire response (Yes/No) on formaldehyde exposure. Excludes wood-related occupations.; Specific co-exposures included asbestos and wood dust. | Mortality: death certificates, MM: ICD-9 203. | Controlled for age, sex, and smoking.; Co-exposures are not associated with LHP cancers. | Poisson regression (internal comparison) RRs (95% CI).; Latency not evaluated. | MM: 14 (4 exposed); Low power dues to the rarity of exposure. | SUMMARY: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Low sensitivity (few cases).
Stroup et al. (1986) United States; Retrospective cohort mortality study. | 2,239 deceased white male anatomists identified from professional societies who died during 1925–1979.; 91% of death certificates of known deceased obtained.; Average follow-up ≈22.52 years.; All cancer SMR = 0.64. | As a profession, anatomists were highly exposed to formaldehyde as a main ingredient in tissue fixative.; Akbar-Khanzadeh and Mlynek (1997) reported mean formaldehyde concentrations in anatomy laboratories of 1.9 ppm with range (0.3–4.5).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation.; Anatomists may also be co-exposed to stains, benzene, toluene, xylene, chlorinated hydrocarbons, dioxane, and osmium tetroxide. | Mortality: underlying cause from death certificates (ICD-8), HL: 201 Larynx: 161 ML: 205 SNC: 160.; Higher survival rates for HL could undercount incident cases, but average follow-up is more than 22 years. | Controlled for calendar year, age, sex, race compared with U.S. population.; Radiation exposure likely to be poorly correlated with formaldehyde.; Benzene not evaluated as potential confounder but is a risk factor for ML.; Potential for confounding is unknown but could have inflated the observed effect. | SMR (95% CI).; Latency not evaluated. | HL: 0; Larynx: 1; ML: 5 (1 acute, 3 chronic, 1 unspecified); SNC: 0; Low power due to the rarity of cases. | SUMMARY: HL, Larynx, ML, SNC: LOW ↓ (Potential bias toward the null); High potential for selection bias. Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. Confounding possible for ML. Low sensitivity (few cases).
Walrath and Fraumeni (1983); United States; Cohort mortality study.; [underlined: Related study:] Hauptmann et al. (2009) | 1,132 deceased white male embalmers identified from NY state license board. Died 1925– 1980.; Death certificates obtained for 75%. The 25% missing death certificates considered to missing at random because all embalmers were considered to be exposed to formaldehyde. All cancer PMR = 1.11. | As a profession, embalmers were highly exposed to formaldehyde as a main ingredient in tissue fixative.; Kerfoot and Mooney (1975) reported mean formaldehyde concentrations for embalmers in funeral homes of 0.74 ppm with range (0.09–5.26).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: underlying cause from death certificates (ICD-8); HL: 201; LL: 204; ML: 205.; Higher survival rates for HL and LL could undercount incident cases, but average follow-up is likely more than 15 years as follow up was initiated in 1925 and ceased in 1980. | Controlled for calendar year, age, sex, and race.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | PMR, 95% CI.; Latency was not evaluated for these endpoints. | HL: 7; Larynx: 2; LL: 4; ML: 7; SNC: 0; Low power for LL due to the rarity of cases. | SUMMARY: Larynx, LL, SNC: LOW ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases).; HL, ML: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due lack of latency analysis with attenuation of association.
Walrath and Fraumeni (1984); United States; Cohort mortality study. | 1,007 deceased white male embalmers identified from CA state license board. Died 1925–1980.; Death certificates obtained for 100%.; All cancer PMR = 1.04. | As a profession, embalmers were highly exposed to formaldehyde as a main ingredient in tissue fixative.; Kerfoot and Mooney (1975) reported mean formaldehyde concentrations for embalmers in funeral homes of 0.74 ppm with range (0.09–5.26).; Co-exposures may have included: phenol, methyl alcohol, glutaraldehyde, mercury, arsenic, zinc, and ionizing radiation. | Mortality: underlying cause from death certificates (ICD-8); HL: 201; LL: 204; ML: 205.; Higher survival rates for HL and LL could undercount incident cases, but average follow-up is likely more than 15 years as follow up was initiated in 1925 and ceased in 1980. | Controlled for calendar year, age, sex, and race.; Radiation exposure likely to be poorly correlated with formaldehyde.; Chemical co-exposures are not known risk factors for this outcome. | PMR, 95% CI.; Latency was not evaluated for these endpoints. | ML: 8; Larynx: 2; LL: 4; HL: 0; SNC: 0; Low power due to the rarity of cases. | SUMMARY: HL, Larynx, LL, SNC: LOW ↓ (Potential bias toward the null); Low potential forinformation bias due to uncertainty in exposure assessment (Exposure Group A). Potential for information bias due lack of latency analysis with attenuation of association. Low sensitivity (few cases).; ML: Medium ↓ (Potential bias toward the null); Low potential for information bias due to uncertainty in exposure assessment (Exposure Group A).; Potential for information bias due lack of latency analysis with attenuation of association.
Wesseling et al. (1996); Costa Rica; Cohort study of banana plantation workers. | 26,565 male workers on the payrolls of banana companies as reported to the Social Security Administration between 1972 and 1979. Cohort follow-up in the cancer registry from 1981 to 1992.; Losses to follow-up and poor record keeping resulted in difficulty in assessing participation rates. Very low confidence in data quality.; Average follow-up ≈11.83 years.; All cancer SIR = 0.76 (men). | A list of names of workers sterilized by dibromochloropropane was used to identify banana plantations whose workers may have been exposed to formaldehyde.; Co-exposed to maneb, dibromochloropropane, mancozeb, benomyl, chlorothalonil. | Incidence: National Tumor Registry.; HL: ICD-9 965-966; MM: ICD-9 973.; Higher survival rates for HL and LL could undercount incident cases, but average follow-up is 12 years. | Controlled for age and sex.; Banana plantation workers are coexposed to several potential carcinogens such as dibromochloropro pane, maneb, mancozeb, benomyl, and chlorothalonil.; While these chemical co-exposures are not known risk factors for these outcomes the fact that co-exposures were so high as to cause sterility in workers strongly suggests a large potential for confounding. | SIR (95% CIs).; Latency was not evaluated for these endpoints. | Males:; HL: 9 cases; MM: 6 cases | SUMMARY: NOT INFORMATIVE Critical limitations: (Selection bias, information bias, confounding)

Table B-60 Evaluation of case-control studies of formaldehyde and cancers of the URT (NPC, SN, OHPC) and LHP (HL, MM, LL, ML)

Reference, setting, and design | Participants, selection, and comparability | Exposure measure and range | Outcome measure | Consideration of likely confounding | Analysis and results (estimate and variability) | Study sensitivity | Evaluation of major bias categories
Armstrong et al. (2000); Malaysia; Population-based case-control study of NPC. | Prevalent and incident NPC cases (31% female) during 1987–1992 identified through treatment or diagnosis records from 4 radiotherapy centers.; Participation of cases was 53% due to death and illness and difficulty in locating them. Participation of living cases who could be located was 89% (n = 282) eligible controls (n = 282).; Selection bias possible. Cases and controls were matched on age, sex, Chinese ethnicity, and neighborhood.; Participation rate was somewhat lower in more affluent neighborhoods (80% vs. 90%). | Individual-level exposure status based on occupational history obtained by interview including job description, worked performed, calendar time, machines, tools, substances used, and exposures to dusts, smoke, gases, and chemicals.; Exposure assessment blinded to outcome.; 8/564 subjects (1.4%) had more than 10 years of potential exposure outside of a 10-year latency period. This suggests additional information bias. | Prevalent and incident cases. Diagnosis of NPC: confirmed by histological review. All cases were squamous cell carcinomas. | Design controlled for age, sex, Chinese ethnicity, and neighborhood.; Analysis adjusted for social class, diet, smoking, and wood dust.; Other exposures evaluated were wood dust, industrial heat, textile dusts, metals, acids, bases, solvents, detergents, and soaps.; Wood dust is a potential confounder but was controlled for. | Conditional logistic regression; ORs (95% CI) for each of 22 separate occupational exposures.; Latency was evaluated (exposures < 1, 5, 10, 15, and 20 years prior to diagnosis). | NPC: 282; The power to evaluate formaldehyde as a hazard is diminished as fewer than 10% of cases had any exposure to formaldehyde and 1.4% had exposure beyond a 10-year period. | Selection issue with substantial difference in participation rates.; Exposure Group B Lack of latency data.; Combination of rarity of exposure among cases with adequate latency resulted in very low power to detect any effects beyond a 10-year period.; SUMMARY: NOT INFORMATIVE (Critical limitation: information bias)
Berrino et al. (2003) Europe; Population-based case-control study of larynx and hypopharynx cancer. | Male residential populations of 6 cancer registries in 4 European countries during 1979– 1982.; All patients with newly diagnosed cancer were identified with participation rates of 70% to 92% by center. Controls participated at an average rate of 74%. Controls were selected from age and sex stratified random samples of the local general population. | Individual-level exposure status based on lifetime occupational history for all jobs held for more than 1 year obtained from questionnaire including job title, specific tasks, and calendar time. Multiple exposure metrics including peak, average, and cumulative exposure developed by job exposure matrix.; However, the quality of the exposure assessment is further degraded by the authors’ statements. Namely, the authors regarded the “JEM performance as poor for formaldehyde where 14% of jobs classified as category 1 (unexposed) by the matrix were judged as definitely exposed by the experts.” Co-linearity among crude exposures (e.g., solvents and formaldehyde had Spearman correlation of 0.4). | Incident cases. Diagnosis of cancer of the larynx or hypopharynx confirmed by pathology review.; Cancer of the larynx divided into epilarynx and endolarynx. Analyses of hypopharynx grouped together with epilarynx while endolarynx analyzed separately.; No separate analysis of hypopharynx without epilarynx. | Controlled for age and sex by selecting controls from stratified population samples.; Analysis controlled for study center, age, tobacco smoking, socioeconomic status, alcohol, and diet.; Exposures to other compounds were identified and evaluated as risk factors including asbestos, arsenic, solvents, and dusts (wood and other). Note that solvents were a stronger risk factor for laryngeal cancer than formaldehyde (OR=2.21 vs. 1.7).; Co-exposures were controlled for but poorly measured covariates cannot be well controlled for. | Unconditional logistic regression; OR (95% CI).; Lagged exposures were evaluated to account for cancer latency in selected analyses. | Larynx (endolarynx): 213 total cases; 37 cases exposed at least 10 years and more than 20 years since first exposure. | Exposure Group B downgraded to Group D based on poor performance of JEM.; Confounding likely due to collinearity of exposures to other risk factors and potentially poor-quality exposure data which minimized ability to control.; SUMMARY: NOT INFORMATIVE Critical limitation: Confounding
Blair et al. (2001) United States; Population-based case control of leukemia. | White men, ages ≥ 30 years. Cases (n = 513) identified 1980–1983 (cancer registry and hospital network). Controls (n = 1,087) selected by random digit dialing (under age 65) otherwise from lists provided by the HCFA and state death files.; Controls were frequencymatched by 5year age groups, vital status at interview, and state of residence.; Cases participation rate was 86%. Control participation rate was 77–79%. | Individual-level exposure status based on lifetime farm and nonfarm occupational history for all jobs held for more than 1 year obtained from interview including job title, industry, and calendar time.; Other exposures evaluated included benzene, other organic solvents, petroleum-based oils & greases, cooking oils, ionizing radiation, paper dusts, gasoline and exhaust vapors, paints, metals, wood dust, asbestos, asphalt, cattle, meat, solder fumes. | Incident cases. Diagnosis of myeloid leukemia and lymphatic leukemia confirmed by pathology review. | Analysis controlled for age, state, direct or surrogate interview, and smoking.; Other co-exposures were not evaluated as potential confounders. | Logistic regression; ORs (95% CI) by exposure categories (3 levels) for intensity, probability, duration, and time since first exposure measures.; Latency not evaluated. | ML: 22/59 exposed (14 acute; 8 chronic); LL: 30/190 exposed | SUMMARY: LL, ML: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Confounding possible.
D’Errico et al. (2009) Italy; Hospital-based case-control study of SNC in the Piedmont region of Italy. | 154 sinonasal cases during 1996–2000 identified through treatment or diagnosis records from all Piedmont hospital departments. 5 cases excluded (3 prevalent cases, 2 <30 years old).; Participation of incident cases using full questionnaire was 76% (113/149). Participation of eligible hospital controls (n=336) was 95%.; Controls frequency matched for age, sex, and province of residence. | Lifetime job history (all jobs); company, job title, tasks, size of work environment, and other details.; Probability of exposure was determined by blinded expert staff for jobs lasting 6 or more mos.; Other exposures evaluated were arsenic, wood dust, leather dust, nickel, chromium, PAHs, welding fumes, oil mists, flour dust, cocoa powder, silica, coal dust, textile dusts, acid mists, paint mists, organic solvents. | Incident cases by cell type were taken from the regional Sinonasal Cancer Registry reported to them by hospitals in the region. | Analysis controlled for age, sex, province of residence, smoking and co-exposures.; Wood dust is a considered an extremely strong risk factor for SNC and a potential confounder and was controlled for but adjusted results not presented; just “loss of statistical significance.” | Unconditional logistic models; ORs (95% CI).; Latency was evaluated with a 10-year latency period. | SNC: 7/113 exposed; The power to evaluate formaldehyde as a hazard is diminished as fewer than 10% of cases had any exposure to formaldehyde. | Exposure Group B; Wood dust is a likely confounder and no effect estimate adjusted for wood dust was presented.; Low power; SUMMARY: NOT INFORMATIVE Critical limitation: Confounding
Gérin et al. (1989) Canada; Population-based case-control study.; [underlined: Related study:] Siemiatycki et al. (1987) | 3,726 male cases, 1979– 1985, from 14 major area hospitals, which report to the Quebec Tumor Registry (97% of all cancers reported). 533 population controls participated out of 740 selected (72%).; Interviews and questionnaires completed for 82% of eligible cases of which 18% of interviews were completed by next of kin.; Internal and external comparison.; Controls were patients with cancer at other sites with all lung cancers excluded.; External comparison with general population. | Lifetime job history included company activities, raw materials and final product, machines, tasks involving machine maintenance, type of room.; A team of chemists and hygienists (likely blinded to outcome) translated each job into a list of potential formaldehyde exposures based on their confidence level, the frequency, and the duration of exposure. | Incident cases histologically confirmed diagnosis of Hodgkin lymphoma (ICD: 201). | Controlled for age, ethnic group, socio-economic status, smoking, and dirtiness of jobs held (white vs. blue collar).; Additional control for any of 300 of the most common occupational exposures if the inclusion changed the formaldehyde OR by more than 10%. | Logistic regression; OR (95% CI).; Latency not evaluated. | HL: 8/53 exposed. | SUMMARY: HL: MEDIUM ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and lack of latency analysis with attenuation of association.
Gustavsson et al. (1998) Sweden.; Population-based case-control study of squamous cell carcinoma of oro-/hypo-pharynx. | 138 men between 40-79 years old residing in Sweden identified by hospitals reports or regional cancer registries with squamous cell carcinoma of oro-/hypo-pharynx during 1988-1990.; Controls were randomly selected from population registries and frequency-matched by sex, age and region.; Interviews completed for 90% of cases and 85% of controls. | Detailed occupational history obtained through unblinded interview yielding information on all jobs held >1 year, starting and stopping times, job title, tasks, and company.; Histories reviewed by a blinded industrial hygienist who coded jobs based on intensity and probability of exposure to 17 occupational factors. | Incident cases of squamous cell carcinomas of the oro-/hypo-pharynx. Diagnosis of cancer based on ICD-9 codes 146 (oropharynx) and 148 (hypopharynx) but not including code 147 (nasopharynx) on weekly reports from departments of otorhinolaryngology, oncology, and surgery and from regional cancer registries. | Controlled for sex, age, region, drinking, and smoking.; Other exposures evaluated included: polycyclic aromatic hydrocarbons, asbestos, quartz, dusts (general, leather, wood, metal, paper, textile), oil & acid mists, phenoxy acids, welding fumes, manmade mineral fibers, nickel, hexavalent chromium.; Co-exposures were not evaluated as potential confounders. | Unconditional logistic regression; RRs (95% CI).; Latency not evaluated. | OHPC: 13/138 exposed.; The power to evaluate formaldehyde as a hazard is diminished as fewer than 10% of cases had exposure to formaldehyde. | SUMMARY: OHPC, Larynx: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association. Confounding possible. Low sensitivity (exposure was rare).
Heineman et al. (1992). Denmark.; Cancer registry-based case-control study, MM diagnosed 1970–1984. | 2,098 men registered in both the national cancer registry and pension fund. All men with a specific occupational history were included.; Controls frequency matched on age, sex, and year of diagnosis. | Individual-level exposure estimated by industrial hygienists based on occupation listed on most recent tax documents. | Incident cases identified in Danish Cancer Registry. 92% of cases were histologically confirmed. | Controlled for age and gender.; Other compounds were identified and evaluated as independent risk factors including: gasoline, oil products, engine exhausts, benzene, dyes, phthalates, vinyl chloride, asbestos, and pesticides.; Asbestos is not a risk factor for LHP.; ‘Possible’ benzene exposure was associated with MM but not ‘probable’ Benzene exposure, so confounding is considered to be unlikely. | Logistic regression, ORs (95% CI) by likelihood of exposure in 3 categories.; Latency not evaluated. | MM: 835 (185 exposed). | SUMMARY: MM: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association.
Hildesheim et al. (2001). Taiwan.; Population-based case-control study.; Related studies: Yang et al. (2005); Hildesheim et al. (1997); Cheng et al. (1999) | 375 men and women with NPC and 375 controls. Ages <75 years, July 1991 and January 1995, from 2 hospitals.; Participation of eligible cases was 99% and 87% for controls. Controls individually matched 1:1 on age, sex, and district/townsh ip of residence. | Lifetime job history (jobs held for at least 1 year since age 16); job title, typical activities/duties, type of industry, and tools and/or materials used.; Industrial hygienist assigned scaling to subjects based upon intensity and probability of exposure on a scale from 0–9. | Incident cases. Diagnosis of nasopharyngeal was confirmed by histological review with >90% diagnosed with nonkeratinizing and undifferentiated carcinomas and 9% with squamous cell carcinoma. | Adjusted for age, sex, education, ethnicity, and HLA. Did not adjust for residence.; Other exposures identified included: wood dust, solvents, and smoking. All subjects were tested for EBV.; The observed associations were not materially affected when controlling for wood dust, smoking and solvent exposure. | Logistic regression; ORs (95% CI) by exposure intensity, exposure probability, cumulative exposure and an induction period of 10 years used to account for latency.; Conditional logistic regression was not used; however, logistic regression did control for age and sex. Area of residence was expected to be related to referral patterns and may not be related to exposure independent of occupational history. | NPC: 375 cases (74 ever exposed) | SUMMARY: NPC: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group B) with attenuation of association.
Laforest et al. (2000) France; Hospital-based case-control study of hypopharyngeal and laryngeal cancer. | Male cases (201 primary hypopharyngea l squamous cell cancer, 296 laryngeal cancer), diagnosed during 1989– 1991, from 15 French hospitals.; Interviews completed for 79.5% of eligible cases and 86% of eligible controls. Controls frequency matched on sex, age, and the same or similar nearby hospital. | Occupational histories from questionnaires; industry and occupation coding used with job exposure matrix for formaldehyde (and other exposures).; Exposure assessment based on jobexposure matrix that included level and probability of exposure to formaldehyde as well as duration and cumulative exposure to formaldehyde. | Incident cases. Diagnosis of hypopharyngeal and laryngeal cancers was histologically confirmed. | Controlled for sex, age, alcohol, and smoking.; Induction periods of 5, 10, and 15 years was also used to account for latency in evaluating risk.; Other exposures evaluated included: coal dust, leather dust, wood dust, flour dust, silica, and textile dust.; Of these, only coal dust significantly increased the risk of hypopharyngeal cancer in this study but coal dust was controlled for in the OHPC analysis. | Unconditional logistic regressio OR (95% CI).; Latency was evaluated. | OHPC: 201; Larynx: 296 | SUMMARY: OHPC, Larynx: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association.
Luce et al. (2002) China, France, Germany, Italy, Sweden, United States; Zheng et al. (1992); Vaughan et al. (1986a, 1986b); Vaughan (1989); Vaughan and Davis (1991); Merler et al. (1986); Magnani et al. (1993); Luce et al. (1992); Luce et al. (1993); Leclerc et al. (1994); Hayes et al. (1986b); Hayes et al. (1986a); Hardell et al. (1982); Comba et al. (1992a); Comba et al. (1992b); Bolm-Audorff et al. (1990) Mack and Preston-Martin (unpub. data) Brinton et al. (1984); Brinton et al. (1985) | Pooled analysis of 12 case-control studies. Men and women. All from 7 different countries diagnosed with sinonasal cancer during 1968–1990. Each individual study selected controls intended to be comparable to the cases in that study. | Occupational histories from interview or questionnaires; industry and occupation coding used with job exposure matrix for formaldehyde (and other exposures). | Diagnoses originally assessed in 12 studies. 195 cases were adenocarcinomas (169 men and 26 women) and 432 were squamous cell carcinomas (330 men and 102 women). | Adenocarcinoma results in men controlled for age, study, and cumulative exposure to wood and leather dust. All other results adjusted for age and study.; Co-exposures were evaluated as potential confounders.; Other occupational exposures potentially affecting risk estimates were controlled for including dusts (wood, leather, coal, flour, textile), silica, asbestos, and man-made vitreous fibers. | Unconditional logistic regressio OR (95% CI).; Latency evaluated. | SNC: 627 cases (135 adenocarcinoma s exposed. 132 squamous cell carcinomas exposed) | SUMMARY: SNC: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association.
Mayr et al. (2010) Germany; Hospital-based case-control study. | Hospital patients diagnosed at the University of Erlangen-Nuremburg, Germany during 1973– 2007.; 31 of 58 patients with identified adenocarcinom a (53%) were followed up with a standardized questionnaire. 85 of 110 patients with cancer of the oral cavity (77%) included as controls. Controls were other hospital patients diagnosed with oral cancer during the same time period as cases and in the same hospital.; Oral cancer could be related to formaldehyde exposure but this would bias towards the null. | Structured interview with specific questions about exposure to formaldehyde (and other exposures). Both cases and controls were blinded to case status and study hypotheses, and were not aware of their “case” status. | Prevalent cases. Diagnosis of sinonasal adenocarcinoma in the Department of Otolaryngology, Head and Neck Surgery. | Controlled for age and sex.; Other exposures: Wood dust, preservatives, stains, varnishes, solvents, and pickling solutions.; Wood dust is a considered an extremely strong risk factor for SNC was not controlled for so there is a strong possibility of confounding. | Crude ORs (95% CI).; Methods unstated for OR determinations.; Latency not evaluated. | SNC: 2/31 exposed; Low power due to the rarity of exposure. | Potential selection issue (prevalent cases); Exposure Group C Latency not evaluated; Wood dust is a likely confounder.; SUMMARY: NOT INFORMATIVE; Critical limitation: Confounding
Olsen and Asnaes (1986b); Denmark; Cancer registry-based case-control study, SNC diagnosed 1970-1982.; [underlined: Related study:] Olsen et al. (1984) | 310 men with incident SN cancer. 215 (69%) squamous cell & lymphoepitheli oma. 39 (13%) adenocarcinom a.; 2,465 controls, selected among people with colon, rectum, prostate, and breast cancer diagnosed during the same time period as cases. Controls were selected to be similar with regard to age, sex, and year of diagnosis. | Employment histories from 1964 based on linkage to population registry data; includes industry and job title.; Occupational exposure to formaldehyde estimated by industrial hygienists based on industry or occupations. | Incident cases identified in Danish Cancer Registry. Cancer of the nasal cavity (ICD-7 160.0) or sinuses (ICD-7 160.2– 160.9) was histologically confirmed. Of all male cases for cancer of the nasal cavity and paranasal sinuses. 82% were squamous cell, lymphoepithelioma 18% were other types. | Matched for age, sex, and year of diagnosis. Mantel-Haenszel summary estimates of the relative risk were used to account for possible confounding because the subjects were stratified according to several variables.; Wood dust is a considered an extremely strong risk factor for SNC so exposure to wood dust was evaluated as a potential confounder and as an effect modifier. | OR (95% CI) calculated using the method of Rothman and Boice (1979).; Latency was evaluated. | SNC: 215 squamous cell and lymphoepitheliomas (13 exposed to formaldehyde) and 39 adenocarcinomas (17 exposed to formaldehyde) | SUMMARY: SNC: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association.
Olsen et al. (1984) Denmark; Cancer registry-based case-control study, NPC diagnosed 1970–1982.; Related study: Olsen and Asnaes (1986b) | 266 incident NPC and 488 incident SN cases; matched approximately 3 controls per case.; Controls matched on age, sex, and year of diagnosis from the Registry. | Employment histories from 1964 based on linkage to population registry data; includes industry and job title. Occupational exposure to formaldehyde estimated by industrial hygienists based on industry or occupations.; Authors reported that 4.2% of control males and 0.1% of females were exposed to formaldehyde. | Incident cases identified in Danish Cancer Registry. NPC: ICD 146 SN: ICD 160.0 and 160.2–160.9 9% of NPC and SNC cases were sarcomas and 91% were carcinomas. Sarcomas were excluded but gender-specific case counts were not provided for carcinomas. | Controlled for age, sex, and year of diagnosis from the registry.; Other exposure evaluated included: wood dust, paint, lacquer, and glue.; Wood dust is associated with SNC and was evaluated as a potential confounder of NPC but was not a risk factor. | OR (95% CI) calculated using programs developed by Rothman and Boice (1979).; Latency was evaluated. | NPC: 266 cases (number exposed is not stated); SNC: cases included in Olsen and Asnaes (1986a). | SUMMARY: NPC: MEDIUM ↓(Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association.
Pesch et al. (2008) Germany; Insurance-based case-control study. | Male workers insured by a liability insurance association for the German wood-working industries with an occupational disease during 1994–2003.; 86/129 cases (67%) participated (including 29 next of kin). 204/272 controls (75%) participated (including 69 next of kin). Controls were selected from the same insurance database of workers with registered accidents. Controls were crudely frequency matched on age with a cut-off at 60 years.; Median ages were both 69 years with cases ranging from 41–84 years and controls ranging from 37–85 years). | Lifetime job history, with focus on tasks and exposures in wood industries.; Because next-of-kin information on exposure to wood additives was considered poor, the probability of exposure to formaldehyde was rated by an expert team as none, low, medium, or high. | Prevalent cases. Cases were ever employed in German wood industries and diagnosed with histopathologically confirmed sinonasal adenocarcinoma.; Because cases and controls were stratified by age less than 60 years and greater or equal to 60 years, the older cases may have been selected for survival. If so, this may have resulted in a downward bias. | Controlled for age, smoking, region, interviewee, and average wood dust exposure.; Co-exposure to wood preservatives, varnishes, and pigment stains likely.; Wood dust is a considered an extremely strong risk factor for SNC but was controlled for. | Logistic regression. OR (95% CI).; A 5-year latency period was applied. | SNC: 47/86 cases exposed | SUMMARY: SNC: LOW ↓ (Potential bias toward the null); Selection bias possible. High potential for information bias due to uncertainty in exposure assessment (Exposure Group B) and weak latency analysis with attenuation of association.
Pottern et al. (1992) Denmark; Cancer registry-based study, MM diagnosed during 1970–1994. | 363 female incident cases; included if found in pension fund registry. 1,517 age and sex matched controls alive at time of case diagnosis.; All women with a specific occupational history other than “Homemaker” were included. | Individual-level exposure estimated by industrial hygienists based on occupation listed on most recent annual income tax documents and the industry associated with that occupation. | Incident cases identified in Danish Cancer Registry. ICD code at time of diagnosis. | Controlled for age, sex, and vital status.; Other exposures evaluated included 19 categories grouping 47 substances.; Co-exposures were not evaluated for confounding but exposure to organic solvents (including benzene) and radiation were not risk factors for MM. | Logistic regression, ORs (95% CI) by likelihood of exposure in 3 categories.; Latency not evaluated. | MM: 60/363 exposed | SUMMARY: MM: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) and lack of latency analysis with attenuation of association.
Roush et al. (1987) United States; Population-based case-control study. | 173 male cases of NPC, 198 male cases of sinonasal cancer identified from the Connecticut Tumor Registry who died during 1935–1975; and 605 male controls dying during the same time period and randomly selected from state death certificates. Controls were matched on sex, date of death, and state of residence. | Job history obtained by city directories and death certificates, which yielded information on job, industry, employer, and year of employment. Job data sought for 1, 10, 20, 25, 30, 40, and 50 years prior to death.; An industrial hygienist, blinded to case status, classified likely exposure to formaldehyde on basis of job title. | Incident cases (from state tumor registries) who had died. Diagnosis of nasopharyngeal cancer and sinonasal cancer based on case registration by the Connecticut Tumor Registry.; Clinical records reviewed for >75% of cases. Histological typing not reported. | Controlled for age at death, year at death, and availability of occupational information.; Exposure to wood dust was not found to be a risk factor for all nasal cancers (NPC+SNC). This suggests a lower potential for confounding by wood dust. | Logistic regression; ORs (95% CI).; Intensity of the likelihood of exposure and latency evaluated. | NPC: 21/173 exposed; SNC: 21/198 exposed | SUMMARY: NPC, SNC: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association.
Shangina et al. (2006) Europe; Multicenter case-control study. | 316 male cases of laryngeal cancer between the ages of 15–79 years residing in 4 European countries that were diagnosed during 1999– 2002 and identified by study centers in Romania, Poland, Russia, and Slovakia. 728 male hospital controls selected within 6 mos of case recruitment from diagnoses excluding disease related to alcohol or tobacco. Controls frequency matched by age +/− 3 years. | Occupational histories obtained by interview and yielded information on all jobs held >1 year. A general questionnaire obtained information of job titles, tasks, industries, starting and stopping times, full-time/part-time status, working environments, and specific exposures. A specific questionnaire was completed for employment in defined jobs or industries. | Diagnosis of laryngeal cancer was histologically or cytologically confirmed and included topographic subcategories from ICD-O code C32 (glottis, supraglottis, subglottis, laryngeal cartilage, overlapping lesion of the larynx, and larynx, unspecified). | Controlled for age, country, smoking, and alcohol.; Other exposures that were found to be risk factors included dusts of “hard alloys” (16 cases) and chlorinated solvents (15 cases).; As formaldehyde, hard alloy dust and chlorinated solvents were each found in fewer than 6% of cases, the correlation between them is considered to be small enough to make confounding unlikely. | Logistic regression; ORs (95% CI).; Latency was evaluated. | Larynx: 18/316 exposed; The power to evaluate formaldehyde as a hazard is diminished as fewer than 10% of cases had any exposure to formaldehyde. | SUMMARY: Larynx: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Low sensitivity (exposure was rare).
Talibov et al. (2014) Europe; Multicountry case-control study. | Individuals from Finland, Iceland, Norway, and Sweden who were recorded in various censuses from 1960–1990. Acute myeloid leukemia cases identified by national registries up until 2003– 2005 depending on the country. | Occupational history from census records were linked to the Nordic Occupational Cancer Study (NOCCA) JEM to code each cohort member as exposed to formaldehyde. Exposures were quantified based on the proportion of people in each occupation considered to be exposed and the mean level of exposure during specific time periods.; 8% of AML cases and controls were exposed.; Co-exposures to solvents was evaluated. | Diagnosis of incident cancer reported to the National Cancer Registries. | Controlled for age (<50, 50+), sex, and solvents.; Solvents included: aliphatic and alicyclic hydrocarbons, aromatic hydrocarbons, benzene, toluene, trichloroethylene, 111-trichloroethane, methylene chloride, perchloroethylene, other organic solvents, and ionizing radiation. | HRs (95% CI).; A 10-year latency period was assumed. | AML: 1201/15,332 exposed | SUMMARY: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association.
Teschke et al. (1997) Canada; Population-based case-control study of nasal cancer. | 48 incident cases of nasal cancers (31% female) older than 19 years, 1990–1992. Controls were randomly selected from age and sex strata of voter list of the same time period.; 6 of 54 cases (11%) were excluded for lack of interview as were 36 of 195 controls (18%).; Controls matched on age and sex. | Standardized questionnaire including occupational, residential, smoking, and medical histories aimed at identifying exposures considered to be probably carcinogenic by IARC.; Occupational data reviewed by an industrial hygienist blinded to cases-tatus.; EPA considered that workers in the textile and pulp and paper mill industries may have been exposed to formaldehyde but the exposure questionnaire did not identify them as exposed.; Pulp and paper mill workers may also be co-exposures to dioxin or perchloroethylene (Kauppinen et al., 1997). | Incident cases from British Columbia Cancer Agency registry. Histologically confirmed primary malignant tumors of the nasal cavity. SNC: ICD-O 160. | Controlled for age and sex.; More than 40 specific occupational groups were evaluated without control of confounding.; Confounding not evaluated.; Potential confounders for these outcomes include chlorophenols, acid mists, dioxin, and perchloroethylene and would likely be positively correlated with formaldehyde exposure. However, on acids mists are associated with URT cancers.; Potential for confounding is unknown but could have inflated the observed effect. | ORs (95% CIs).; Latency was evaluated. | SNC: 48 3 cases exposed to pulp and paper mills. | SUMMARY: SNC: LOW ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association. Potential confounding. Low sensitivity (rare exposure).
Vaughan et al. (2000) United States; Population-based case-control study of nasopharyngeal cancer. | 196 cases (32% female) ages 18–74 diagnosed during 1987– 1993 identified from 5 population based cancer registries.; Interviews completed for 82% of cases and 76% of the 244 controls.; 19% of case interviews completed by next of kin.; Controls selected by random digit dialing in the same geographical region frequency matched by age, sex, and cancer registry. | Individual-level exposure based on industrial hygienist review of detailed occupational histories including industry, job title, duties and dates used to estimate probability, intensity, and cumulative exposure. | Incident cases. Diagnosis of nasopharyngeal (any histological type) based on clinical records.; Histological typing reported. | Controlled for age, sex, race, registry, smoking, proxy status, and education.; Wood dust evaluated as an independent risk factor for NPC controlling for formaldehyde and it was not a risk factor in this data set. Therefore, wood dust should not be a confounder in this data set. | Logistic regression; ORs (95% CI) by probability of exposure, duration, and cumulative exposure.; Separate analyses by histological type.; Latency evaluated. | NPC: 79 exposed cases. | SUMMARY: NPC: MEDIUM ↓(Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group B) with attenuation of association.
Vaughan (1989) United States; Population-based, case control study of squamous cell cancers of the pharynx and sinonasal cavity.; [underlined: Related studies:] Vaughan et al. (1986a 1986b); Included in Luce et al. (2002) | 231 cases (32% female) ages 20–74 years residing in the area covered by Washington State Cancer Surveillance System during 1980–1983.; Participation for all cases was 69% (see (Vaughan et al., 1986a)) and 80.0% for controls (n = 552).; ≈50% of cases interviews completed by next of kin. Controls selected by random digit dialing in same residential area as cases and were frequency matched on age and sex with at 2 controls per cases in each 5-year age and sex category. May result in poorer quality exposure data and a bias towards the null. | Individual-level exposure based on job exposure matrix by occupation and industry for each individual job used to estimate probability and intensity of exposure.; Formaldehyde exposure from available industrial hygiene data, NIOSH and other data, and NCI job exposure linkage system.; Occupation as a carpenter or employment in the “lumber and wood product manufacturing” industry presumed to be exposed to formaldehyde. | Incident cases. Diagnosis of squamous cell cancers of the pharynx and sinonasal cavity based on review of hospital medical records, surveillance of radiotherapy and pathology practices, and state death certificates. | Controlled for age, sex, smoking, and alcohol.; NPC analyses controlled for race.; Wood dust is associated with risk of URT cancer and was not evaluated as a confounder. However, as this is a case-control study and the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder. | Logistic regression; ORs (95%CI).; Duration of employment and occupation are surrogates for intensity of exposure.; Latency was evaluated. | NPC: 3/21 exposed OHPC: 11/183 exposed SNC: cases included in Luce et al. (2002).; Low power for NPC. | SUMMARY: NPC: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Low sensitivity (rare exposure).; OHPC: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association.
Vaughan et al. (1986a) United States; Population-based, case control study of cancers (all types) of the pharynx and sinonasal cavity.; [underlined: Related studies:] (Vaughan et al., 1986b); Vaughan (1989) @@author-year; SNC cases included in Luce et al. (2002) but not here. | 285 cases (35% female) ages 20–74 years residing in the area covered by Washington State Cancer Surveillance System during 1980–1983.; Participation for all cases was 69% and 80% for controls (n=552).; ≈50% of cases interviews completed by next of kin. Controls selected by random digit dialing in same residential area as cases and were frequency matched on age and sex with at 2 controls per cases in each 5-year age and sex category. | Individual-level exposure based on job exposure matrix by occupation and industry for each individual job used to estimate probability and intensity of exposure.; Formaldehyde exposure from available industrial hygiene data, NIOSH, and other data, and NCI job exposure linkage system. | Incident cases. Diagnosis of squamous cell cancers of the pharynx and sinonasal cavity based on medical records, surveillance of radiotherapy and pathology practices, and state death certificates.; 2% of cases were nonsquamous cell cancers Vaughan (1989). | Controlled for age, sex, smoking, and alcohol.; NPC analyses controlled for race.; Wood dust is associated with risk of URT cancer and was not evaluated as a confounder. However, as this is a case-control study and the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder. | Logistic regression; ORs (95%CI).; Latency was evaluated. | NPC: 11/27 occupationally exposed.; OHPC: 58/205 occupationally exposed. SNC: cases included in Luce et al. (2002). | SUMMARY: OHPC, NPC: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association.
Vaughan et al. (1986b) United States; Population-based, case control study of cancers (all types) of the pharynx and sinonasal cavity.; [underlined: Related studies:] Vaughan et al. (1986a); Vaughan (1989); SNC cases included in Luce et al. (2002) but not here. | 285 cases (35% female) ages 20–74 years residing in the area covered by Washington State Cancer Surveillance System during 1980–1983.; Participation for all cases was 69% (see (Vaughan et al., 1986a)) and 80% for controls (n=552).; ≈50% of cases interviews completed by next of kin. Controls selected by random digit dialing in same residential area as cases and were frequency matched on age and sex with at 2 controls per cases in each 5-year age and sex category. | Presumed exposure to formaldehyde based on structured telephone interview information on occupational and residential history.; Interview-based information on lifetime residential history from cases, next of kin, and controls. | Incident cases. Diagnosis of squamous cell cancers of the pharynx and sinonasal cavity based on medical records, surveillance of radiotherapy and pathology practices, and state death certificates.; 2% of cases were nonsquamous cell cancers (Vaughan, 1989). | Controlled for age, sex, smoking, and alcohol.; NPC analyses controlled for race.; Wood dust is associated with risk of sinonasal cancer and was not evaluated as a confounder. However, as this is a case-control study and the correlation between formaldehyde and wood dust is expected to be small and thus wood dust would not be expected to be a confounder. | Logistic regression; ORs (95% CI).; Latency was evaluated. | NPC: 8/27 lived in mobile home.; 10/27 exposed to particleboard. OHPC: 28/205 lived in mobile home.; 68/205 exposed to particleboard. SNC: cases included in Luce et al. (2002). | SUMMARY: OHPC, NPC: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association.
West et al. (1993) Philippines; Hospital-based case-control study.; [underlined: Related study:] Hildesheim et al. (1992) | 104 cases (27% female), 11–83 years old, predominantly non-Chinese, from the Philippine General Hospital diagnosed before 1992.; 100% of cases participated. All 104 hospital controls participated while only 77% of 101 community controls participated (Hildesheim et al., 1992). Hospital controls were matched on age, sex, and hospital ward type (private/public).; Community controls were matched on age, sex, and neighbor-hood of residence. | Lifetime job history; details not provided.; Occupational exposure to formaldehyde classified by blinded industrial hygienist as likely or unlikely to be exposed; appendix provides formaldehyde exposure rating for each job category. | Incident cases. Diagnosis of NPC pathologically confirmed by histological review for all cases.; Histological typing not reported. | Controlled for age, sex, hospital ward type (or neighborhood), for education, years since first exposure to dust and exhaust fumes, diet including processed meats, fresh fish, smoking, anti-mosquito coils, and herbal medicines.; Note that antimosquito coils emit formaldehyde 0.87–25 μg/m^3^ (Liu et al., 2003).; Controlling for mosquito coils may have underestimated the effect of formaldehyde. | Conditional logistic regression; ORs (95% CI).; Latency was evaluated. | NPC: 27/104 exposed | SUMMARY: NPC: MEDIUM ↓; (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association.
Wortley et al. (1992) United States; Population-based, case control study of cancers (all types) of the larynx. | 235 cases (21% female) ages 20–74 years residing in the area covered by Washington State Cancer Surveillance System during 1983–1987.; Participation for all cases was 81% and 80% for controls (n=547).; 7% of cases interviews completed by next of kin. Controls selected by random digit dialing in same residential area as cases and were frequency matched on age and sex with at 2 controls per cases in each 5-year age and sex category. | Individual-level exposure based on job exposure matrix by occupation and industry for each individual job used to estimate duration and intensity of exposure.; Formaldehyde exposure from available industrial hygiene data, NIOSH, and other data, and NCI job exposure linkage system. | Incident cases. Diagnosis of cancer of the larynx based on medical records, surveillance of radiotherapy and pathology practices, and state death certificates.; 94.5% of cases were squamous cell cancers. | Controlled for age, smoking, and alcohol. Further adjustment for sex did not change results.; Other exposures: asbestos, chromium, nickel, cutting oils, and diesel fumes. High risk occupations (e.g., mechanics, carpenters, painters, textile machine operators) likely had co-exposures to unidentified substances.; However, as this is a case-control study the correlation between formaldehyde and those potential confounders is expected to be small and thus wood dust would not be expected to be a confounder. | Logistic regression; ORs (95%CI).; Latency was evaluated. | Larynx: 58/235 occupationally exposed | SUMMARY: Larynx: MEDIUM ↓ (Potential bias toward the null); Potential for information bias due to uncertainty in exposure assessment (Exposure Group C) with attenuation of association.
Yang et al. (2005) Taiwan; Family-based case-control study.; [underlined: Related studies:] Hildesheim et al. (1997); Hildesheim et al. (2001); Cheng et al. (1999) | 502 cases recruited from 265 families with 2 or more NPC cases identified from earlier study (Hildesheim et al., 2001). Additional cases obtained from hospitals that treat NPC. Occupational data available for 65% of cases and 57% of controls. 203 cases represented by next of kin (>40%).; Cases were matched with 2 groups: First with 1,944 familial controls; and second with 327 population controls. | Lifetime job history (jobs held for at least 1 year since age 16); job title, typical activities/duties, type of industry, and tools and/or materials used. Exposures coded by industrial hygienist.; Exposures in 10 years preceding diagnosis of interview were excluded.; Collected information on cigarette smoking, betel nut consumption, wood and formaldehyde exposure, and Guangdong and other salted fish consumption during childhood. | Original case series were incident cases. Unclear if supplemental cases were incident or prevalent. Diagnosis NPC confirmed by histological review on 502 cases from national tumor registry. | Three analyses (check each and be specific).; Family control analysis controlled for family, age, sex, education, and ethnicity.; This analysis did not control for partial matching on education, ethnicity, or area of residence. Nor did it control for smoking, betel nut consumption, or wood.; In this study, smoking was inversely associated with NPC. Because smoking is positively associated with formaldehyde, there may be negative confounding by smoking in this study. | Unconditional logistic regression (95%CI) controlling for age and sex.; Lagged exposure partially address latency.; Controls used here were originally matched to an earlier set of cases, some of whom were included here. | NPC: 502 | SUMMARY: NPC: LOW ↓ (Potential bias toward the null); Potential selection bias. High potential for information bias due to uncertainty in exposure assessment (Exposure Group D) with attenuation of association. Confounding possible.
Yu et al. (2004) Hong Kong; Mortality odds ratio.; [underlined: Related studies:] Ho et al. (2006); EHS Consultants Ltd. (1999) | Men and women.; Restaurant workers (n=1,225) who died during 1986–1995 and were registered as union members by 4 major Chinese-style restaurant workers’ unions in Hong Kong. Cause of death available for more than 80% of restaurant workers. | Occupational history obtained from union records. 415 deceased waiters and 140 deceased waitresses and kitchen workers likely exposed to formaldehyde based on independent studies of air quality in service areas of restaurants. Authors discuss sources of exposure.; Co-exposures include Epstein-Barr virus (EBV), smoking, salted and preserved foods, and other combustion by-products. | Mortality: Underlying cause of death from Hong Kong Census and Statistics Department. NPC: ICD-9 147 Histological typing not reported. | MOR with Internal control group adjusted for age at death, sex, year of death, and place of origin. External control group Adjusted for age at death, sex, and year of death.; Most adults (90+ %) are seropositive for EBV and thus it cannot be a confounder. Smoking was evaluated as a potential confounder because 49% of staff smoked compared to 27% of population, but it was insufficient to explain the observed effects.; Authors stated that with free fresh food available to workers, the availability of preserved or salted food was unlikely to explain the observed effect. | Logistic regression. Mortality odds ratios (MORs) calculated for waiters and waitresses by internal and external control and for waiters, length of union membership (a surrogate for duration of exposure).; Latency was not evaluated. | NPC: 21 | SUMMARY: NPC: LOW ↓ (Potential bias toward the null); High potential for information bias due to uncertainty in exposure assessment (Exposure Group C) and lack of latency analysis with attenuation of association. Confounding possible.

#### Animal Studies

Animal studies in Tables B-61 (respiratory tract cancers) and B-62 (LHP cancers) are grouped by exposure duration, and then organized alphabetically by first author. Specific study details (or lack thereof) that highlight a limitation or uncertainty in answering each of the domain criteria are noted in the table cells. For those identified as having a substantial limitation likely to influence the study results (major limitations), the relevant study details are bolded. Italics are used to highlight other limitations not viewed as substantial in the context of respiratory tract pathology (minor limitations). A ‘Good’ domain rating is denoted by ‘++’; an ‘Adequate’ rating by ‘+’; and a ‘Deficient’ rating by gray shading.

##### Respiratory Tract Cancer Study Evaluations

Table B-61 Evaluation of controlled inhalation exposure studies examining respiratory tract cancer or dysplasia in animals

Reference and species | Exposure quality (see Appendix B.3.1) | Test subjects | Study design | Endpoint evaluation | Data considerations & statistics | Confidence classification
Respiratory Tract Cancers—Chronic
(Appelman et al., 1988); Rat | ++ | +; Small N (N=10);; Note: randomized | 1-year duration short to allow for cancer development | +; Blinding of slides for evaluation NR | ++ | Medium; [1 year duration]
(Dalbey, 1982); Hamster | ++; Note: 5 hr/d exposure; days and timing of exposure NR | ++ | ++; Note: single concentration (12.3 mg/m^3^) lifetime study | Blinding of slides for evaluation NR; only 2 nasal sections; limited reporting of histopathology methods; unclear if dysplasia considered | +; Locations and specific incidence of lesions and other minor details NR | Medium; [Limited sampling, evaluation, and reporting]
(Holmstrom et al., 1989b) | ++; Note: high concentration exposure (15.3 mg/m^3^); exposed nocturnally, in contrast to other studies | +; Small N (N = 15–16); some cannibalism; non-URT tumors ≈50% across groups | +; 2/16 animals in formaldehyde group developed emphysema; Note: single concentration (15.3 mg/m^3^) 2 year study | ++; Note: slides blinded | +; Locations of lesions and other minor details NR | Medium; [Some health issues noted; limited reporting]
(Kamata et al., 1997); Rat | +; Formalin exposure, with a methanol control (assumed to be based on levels in formalin); Note: methanol considered unlikely to affect endpoint | +; Small N for interim sacrifices (N = 2–5); Note: mortality rate doubled at 18.3 mg/m^3^; exposure begun at ≈PND35 | ++; Note: 2 year study | +; Blinding of slides for evaluation NR | ++ | Medium; [Formalin (with methanol control)]
(Kerns et al., 1983); Mouse; See also (Battelle, 1982) and (Swenberg et al., 1980b) | ++ | +; Survival to 18 mos was <33% in all groups (N is >25); Note: randomized | ++; Note: data from this study based on a 2 year GLP study (Battelle, 1982) | +; Only three nasal sections evaluated; blinding of slides for evaluation NR | +; Limited reporting of dysplasia findings | High; [Note: somewhat limited sampling and high mortality]
(Kerns et al., 1983); Rat; See also (Battelle, 1982) and (Swenberg et al., 1980b) | ++ | +; Viral infection at weeks 52–53; Note: considered unlikely to influence these outcomes; randomized | ++; Note: data from this study based on a 2 year GLP study (Battelle, 1982) | +; Blinding of slides for evaluation NR; Note: routine analysis of nasal tissues only | +; Limited reporting of dysplasia findings | High; [Note: transient viral infection]
(Monticello et al., 1996); Rat | ++ | ++; Note: randomized | ++; Note: 2 year study | +; Blinding of slides for evaluation NR; Note: routine analysis of nasal tissues only | ++ | High
(Sellakumar et al., 1985); Rat; see also (Albert et al., 1982) | +; Air controls direct into chamber, not through apparatus; Note: PFA in paraffin oil (commonly used in bubbler-type units); high concentration exposure (18.2 mg/m^3^) | ++ | ++; Note: single concentration (18.2 mg/m^3^) lifetime study | +; Blinding of slides for evaluation not specified | ++ | High
(Woutersen et al., 1989); Rat, 28-month exposure | ++ | ++; Note: randomized | ++; Note: 2 year study | +; Blinding of slides for evaluation NR;; Note: routine analysis of nasal tissues only | ++ | High
Respiratory Tract Cancers—Subchronic (note: includes 1 study with only 8 weeks of exposure in genetically modified mice)
(Andersen et al., 2010); Rat | +; Analytic concentrations NR | Small N (N = 8); Note: randomized | 13 wk duration with no follow up to allow for cancer development | +; Blinding NR; limited reporting of slide selection, analysis methods, and number of slides evaluated | + | Low; [Short duration; small sample; short duration of exposure with no follow up]
(Arican et al., 2009); Rat | Analytical method and concentrations NR | +; Small N (N = 10); Note: randomized | 12 wk duration with no follow up to allow for cancer | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [short duration; exposure and outcome methods lacking]
(Casanova et al., 1994); Rat | ++ | Small N (N = 3); Note: randomized | 12 wk duration with no follow up to allow for cancer | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [short duration; small N; outcome methods lacking]
(Coon et al., 1970); Dogs | ++ | Small N (N = 2); limited reporting (e.g., age, weight, health status, etc.) | Multiple species housed and exposed simultaneously; continuous exposure (>22 hr/d); 90d study does not allow for cancer to develop; Notes: single concentration (4.6 mg/m^3^) study | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [outcome methods lacking; short duration; group housed for exposure]
(Coon et al., 1970); Guinea pig | ++ | NR age or number of male vs. female guinea pigs; small N (N = 15); limited reporting (e.g., age, weight, health status, etc.) | Multiple species housed and exposed simultaneously; continuous exposure (>22 hr/d); 90 d study does not allow for cancer to develop; Notes: single concentration (4.6 mg/m^3^) study | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [outcome methods lacking; short duration; group housed for exposure]
(Coon et al., 1970); Monkey | ++ | Small N (N = 3); limited reporting (e.g., age, weight, health status, etc.) | Multiple species housed and exposed simultaneously; continuous exposure (>22 hr/d); 90 d study does not allow for cancer to develop; Notes: single concentration (4.6 mg/m^3^) study | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [outcome methods lacking; short duration; group housed for exposure]
(Coon et al., 1970); Rabbit | ++ | Small N (N = 2); limited reporting (e.g., age, weight, health status, etc.) | Multiple species housed and exposed simultaneously; continuous exposure (>22 hr/d); 90 d study does not allow for cancer to develop; Notes: single concentration (4.6 mg/m^3^) study | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [outcome methods lacking; short duration; group housed for exposure]
(Coon et al., 1970); Rat | ++ | NR number of male vs. female nor how many of each strain exposed; limited reporting (e.g., age, weight, health status, etc.) | Multiple species housed and exposed simultaneously; continuous exposure (>22 hr/d); 90 d study does not allow for cancer to develop; Notes: single concentration (4.6 mg/m^3^) study | Blinding NR; slide selection, analysis methods, and number of slides or regions evaluated NR | +; Qualitative descriptions only | Not informative; [outcome methods lacking; short duration; group housed for exposure]
(Feron et al., 1988); Rat | ++; Note: high concentration exposure (> 12 mg/m^3^) | ++ | +; 13 wk duration, but long-term follow up to allow for cancer to develop | +; Blinding NR; limited reporting of analysis methods | +; Limited information (deaths only) to inform timing of tumor development | Medium; [Short duration of exposure; limited reporting]
(Horton et al., 1963); Mouse | +; Analytic concentrations NR; Note: excessive exposure level (≈200 mg/m^3^) | +; Limited reporting (e.g., age, weight, health status, etc.); high mortality | 35 wk duration with no follow up to allow for cancer; exposure paradigm of 1 hr/wk considered less informative | Nasal tissue not examined; blinding NR; limited reporting | + | Not informative; [Primary target tissue not examined; study design limited]
(Maronpot et al., 1986); Mouse | Formalin, methanol concentrations NR, and no controls | +; Small N (N = 10); Note: randomized | 13 wk duration with no follow up to allow for cancer | +; Blinding NR; limited reporting of analysis methods | ++ | Low; [Formalin; small sample; short duration of exposure with no follow up]
(Morgan et al., 2017); National Toxicology Program (2017) Mouse | +; Analytic concentrations NR | ++; Note: “randomly assigned”; Males only; ≈25 mice/group; genetically modified (p53+/-) | 8 wk exposure duration; follow up for 32 wks; Note: although unclear if exposure or follow up duration was adequate, the study employed maximally tolerated cumulative dose | +; Blinding NR; examined 3 nasal cavity sections (and 1 larynx); Note: 4 additional pathologists reviewed all tumor slides | ++ | Low; [very short (8 wk) exposure duration and limited follow up (32 wk) for cancer development]
(Rusch et al., 1983); Rat | ++; Note: test article was not stabilized (negligible methanol) formaldehyde; concentration <3.6 mg/m^3^ | ++ | 26 wk duration with no follow up to allow for cancer | +; Blinding NR; limited reporting of analysis methods | ++ | Low; [Short duration of exposure with no follow up]
(Rusch et al., 1983); Monkey | ++; Note: test article was not stabilized (negligible methanol) formaldehyde; concentration <3.6 mg/m^3^ | ++ | 26 wk duration with no follow up to allow for cancer | +; Blinding NR; limited reporting of analysis methods | ++ | Low; [Short duration of exposure with no follow up]
(Rusch et al., 1983); Hamster | ++; Note: test article was not stabilized (negligible methanol) formaldehyde; concentration <3.6 mg/m^3^ | ++ | 26 wk duration with no follow up to allow for cancer | +; Blinding NR; limited reporting of analysis methods | ++ | Low; [Short duration of exposure with no follow up]
(Wilmer et al., 1989); Rat | +; Analytic concentrations NR; Note: concentration tested <5 mg/m^3^ | ++; Note: randomized | 13 wk duration with no follow up to allow for cancer development | +; Blinding NR | ++ | Low; [Short duration of exposure with no follow up]
(Woutersen et al., 1987); Rat | ++ | +; Small N (N = 10); Note: randomized | 13 wk duration with no follow up to allow for cancer | +; Blinding NR | ++ | Low; [Short duration of exposure with no follow up]
(Woutersen et al., 1989); Rat, 3-month exposure | ++ | ++; Note: randomized | +; 12 wk duration, but long-term follow up to allow for cancer to develop | +; Blinding of slides for evaluation NR;; Note: routine analysis of nasal tissues only | ++ | Medium
(Zwart et al., 1988); Rat | ++; Note: concentration <3.6 mg/m^3^ | ++ | 13 wk duration with no follow up to allow for cancer | +; Blinding NR | +; Qualitative descriptions only | Low; [Short duration of exposure with no follow up]

NR = not reported; N/A = not applicable.Lymphohematopoietic Cancer Study Evaluations

Table B-62 Evaluation of controlled inhalation exposure studies examining lymphohematopoietic cancers in animals

Reference and species | Exposure quality | Test subjects | Study design | Endpoint evaluation^c^ | Data considerations and statistics | Confidence classification
(Kamata et al., 1997); Rat | +; Formalin exposure, with a methanol control | +; Small N for interim; sacrifices (N = 2–5); Note: mortality rate doubled at 18.3 mg/m^3^; exposure begun at ≈PND35 | ++; Note: 2 year study | +; Blinding of slides for evaluation NR; specific, routine histopathology of several tissues relevant to LHP cancer (e.g., femur) | +; Limited reporting (incidence data for non-nasal lesions not reported) | Medium; [Formalin (with methanol control); limited reporting of LHP cancers]
(Kerns et al., 1983); Mouse; See also (Battelle, 1982) and (Swenberg et al., 1980b) | ++ | +; Survival to 18 mos was <33% in all exposed groups of male mice (N is still >25); randomized | ++; Note: relevant data from the 2-year GLP study report (Battelle, 1982) | +; Blinding of slides for evaluation NR; reported gross lesions only for most exposure levels; slides examined for highest exposure level only | +; Limited reporting (incidences only reported for highest exposure level) | Medium; [limited sampling and reporting of potential LHP cancers; some increased mortality in exposed males]
(Kerns et al., 1983); Rat; See also (Battelle, 1982) and (Swenberg et al., 1980b) | ++ | +; Viral infection at weeks 52–53; (Note: considered unlikely to influence these outcomes); high mortality in highest exposure groups; randomized | ++; Note: relevant data from the 2-year GLP study report (Battelle, 1982) | +; Blinding of slides for evaluation NR; reported gross lesions only for most exposure levels; slides examined for highest exposure level only | +; Limited reporting (incidences only reported for highest exposure level) | Medium; [limited sampling and reporting of potential LHP cancers; high mortality in highest exposure groups; transient viral infection]
National Toxicology Program (2017) (Morgan et al., 2017; Mouse | +; Analytic concentrations NR | ++; Note: “randomly assigned”; Males only; ≈25 mice/group; genetically modified (p53+/-) | 8 wk exposure duration; follow up for 32 wk Note: although unclear if exposure or follow up duration was adequate, the study employed maximally tolerated cumulative dose; however, no increase in any tumors noted (even nasal SCCs, which were the focus of the study hypothesis) | +; Blinding NR; slide evaluation details NR, but assessed multiple relevant tissues; Note: 4 additional pathologists reviewed all tumor slides | ++ | Low; [very short (8 week) exposure duration and limited follow up (32 wk) for cancer development]
(Sellakumar et al., 1985); Rat; see also (Albert et al., 1982) | +; Air controls direct into chamber, not through apparatus; Note: PFA in paraffin oil (commonly used in bubbler-type units); high concentration exposure (18.2 mg/m^3^) | ++ | ++; Note: single concentration (18.2 mg/m^3^) lifetime study | Does not appear to be an explicit, routine examination of tissues relevant to LHP cancers, or an evaluation of bone marrow, in particular (“histologic sections were prepared from… other organs where gross pathology was present”); Blinding of slides for evaluation not specified | ++ | Low; [no routine examination of tissues relevant to LHP cancers, and lack of evaluation of bone marrow specfically, severely limits detection ability]

### B.3.10 Mechanistic Information Related to Genotoxicity and Cancer

Details of the study evaluation approach methods are provided in Section 2.3.10 of the Toxicological Review. As described in Section 2.3.10, many of the studies synthesized for the MOA analyses of respiratory tract and LHP cancers were evaluated in the sections above, most notably Appendix B.3.6. The study evaluations specific to genotoxicity in epidemiology studies are documented in Table B-63 below, with studies organized alphabetically. These study evaluations are discussed further as one component of the broader genotoxicity evaluation in Appendix C.3.

Table B-63 Evaluation of genotoxicity endpoints in epidemiology studies of formaldehyde exposure

Reference and setting | Exposure measures and range | Outcome classification | Consideration of participant selection and comparability | Consideration of likely confounding | Analysis and completeness of results | Study size | Comment
Aglan and Mansour (2018) (Egypt) Hair stylists | Passive air sampling (Umex-100) at fixed position in breathing zone, 15-min samples during hair straightening process; 15-min TWA Group 1 (work duration < 5 years): 1.68 ± 0.27 ppm Group 2 (work duration > 5 years): 1.83 ± 0.16 ppm | Blood collected at end of 8-hr shift on day hair straightening occurred, processed within 6 hrs. Cytokinesis block micronucleus test in lymphocytes Maffei et al. (2002). Replicate cultures for each sample, incubated 72 hrs, cytochalasin-B added for the last 28 hrs. 1,000 binucleated cells examined per person. 2,000 binucleated cells from coded slides (1,000 from each replicate culture), scored using criteria by Fenech et al. (2003). MN frequency % altered cells.; MN in exfoliated buccal cells. Cheeks scraped with wooden spatula, fixed in 3:1 methanol/acetic acid and dropped onto slides. Air dried slides stained with Feulgen/Fast Green, examined at 400× according to Tolbert et al. (1991). Analyzed independently by 2 people, 1,500 cells scored per person using criteria by Sarto et al. (1987) % altered cells. | 60 female hairstylists selected between June 2015 and September 2016, aged 20–36 years with comparable work hours, number of clients, usual tasks included hair straightening and no gaps in employment. Excluded subjects with chronic disease and /or regular medications, family history of cancer, recurrent abortions, smoking or pregnancy. Comparison group was 60 healthy female hair stylists who did not straighten hair “matched age, residency, nutritional habits, and socioeconomic standard.” Participation rates not reported. No data provided to confirm asserted comparability between exposed and referents. | Exposed participants were comparable for work tasks, number of clients and work duration. Only nonsmokers were included, and all were female. Exposed and unexposed were “matched” for age, residency, nutritional habits, and SES. | Comparisons between unexposed, group 1 and group 2 using Kruskal Wallis test for nonnormally distributed variables (MNL and MNB) and least significant difference. Comparisons were across duration (greater or less than 5 years) and 15-min TWA concentrations were higher in Group 2 (p = 0.03, t test). | Unexposed n = 60; Group 1; n = 31; Group 2; n = 29 | Reporting deficiencies result in some concern about potential for selection bias.; Comparisons were for duration of exposure (greater or less than 5 years) and 15-min TWA concentrations also were statistically different in these groups.
Attia et al. (2014) (Egypt) Cosmetic manufacture | Urine formic acid according to Hopner and Knappe (1974); unclear how to relate urine formic acid levels to air concentrations | Peripheral blood; plasma MDA (commercial kit), plasma p53 (p53 enzyme-linked immunosorbent assay kit.; Blinding not stated, but likely minimal bias because interpretation not required | 40 employees at company randomly selected compared to referent (N = 20) selected from hospital administrative department with comparable gender and SES & no history of occupational exposure to formaldehyde | Age differed between exposed and referent, but age and gender were not associated with formate levels, MDA levels, or p53 levels | Analyses of coded data (blinded assumed) Exposed compared to referent, means (Student’s t-test), correlation between urinary formate and MDA or p53 using linear regression | Exposed n = 40, referent n = 20 | No obvious bias
Aydın et al. (2013) (Turkey) Medium density fiberboard plants (prevalence study) | 24 area samples in workplaces; personal samples in breathing zone over 8-hr period. 8-hr TWA calculated | Peripheral blood lymphocytes; samples processed within 6 hr, comet assay, tail intensity, tail moment, and tail migration, alkaline conditions, Singh et al. (1988), cells lysed >1 hr, electrophoresis 20 min, 100 cells/ subject (2 replicates), image analysis software. Blinding not stated | Selection & recruitment of exposed and referent not described. Participation rates not reported. 46 male workers compared to 46 nonexposed males in same area (administrative government offices and maintenance services) | Exposed and referent comparable with respect to age, sex, lifestyle, and smoking habit. No history of occupational exposure to formaldehyde or other chemicals | ANOVA or Kruskal-Wallis H test depending on test for normality; presented mean & SD by exposure group, stratified by smoking status; Results of test for normality were not reported, comet assay endpoints were not lntransformed | Exposed N = 46; Referent N = 46 | No obvious bias
Ballarin et al. (1992) (Italy) Plywood factory | Personal samplers, Sampling in warehouse (N = 3) shearing-press (N = 8) & sawmill (N = 1), sampled formaldehyde and wood dust Calculated 8-hr TWA, reference for measurements (NIOSH, 1977). | Nasal respiratory mucosa cells, cell collection using endocervical brush, smeared onto previously coded slides, stain Feulgen’s reaction plus Fast Green, MN, analysis blinded by one reader for cytogenetic, 6,000 cells/ subject, scoring criteria Sarto et al. (1987) | Selection & recruitment of exposed and referent not described. Participation rates not reported. Referent from different source population: university or hospital clerks; excluded heavy drinkers | All nonsmokers, matched to referent for age and sex | Differences analyzed using Mann-Whitney test | Exposed n = 15; Referent n = 15 | Small sample numbers; no obvious bias
Bauchinger and Schmid (1985) (Germany) Papermaking | Exposure assessment based on air monitoring and job-function. Sampling design and duration was not described. | Peripheral lymphocytes, CA/cell (scored 500 cells/ subject), Giemsa staining; SCE/cell (scored 50/subject) analyzed using coded slides | Selection & recruitment of exposed and referent not described. Participation rates not reported. Exposed and referent worked at same factory | All male, Comparable for age, more smokers among referent; no previous radiation history or exposure to other industrial chemicals | Mann-Whitney rank U test to compare groups, SCE analysis stratified by smoking | Exposed N = 20; Referent N = 20 | Possible bias toward null because no adjustment for smoking in CA analysis
Bono et al. (2010) (Italy) Pathology labs | Personal sampling over an 8-hour shift in each subject; LOD 0.05 μg/m^3^; questionnaire data on job-specific work (work in production room where slides were fixed or other areas) & use of personal protection | M_1_dG adducts in DNA extracted from whole blood, methods described in van Helden et al. (2009); evaluated in 20 out of 40 exposed and 20 out of 32 referent workers (selection criteria were not described) | Selection & recruitment of exposed and referent not described. Participation rates not reported. Recruited workers from 3 pathology labs and workers & students from a university lab with no exposure to formaldehyde | Mean formaldehyde levels varied by age, smoking, and exposure status (referent, work in production room, work in other areas); confounding assessed in analysis | Formaldehyde exposure tertiles based on 8-hr average formaldehyde concentration, compared mean log-transformed M_1_dG adducts by exposure tertile or exposure status, using ANCOVA adjusting for sex, age, smoking; evaluated multiple comparisons using Dunnett tests | Exposed N = 20; Referent N = 20 | No obvious bias; small sample size especially for analysis of effect modification by smoking
Bouraoui et al. (2013) (Tunisia) Anatomy/pathology lab in hospital | Area sample in macroscopic room, diffuse radical samplers containing 2,4-dinitrophenyl-hydrazine, 24-hr duration, 3 samplings. | Cytokinesis-blocked MN assay in peripheral lymphocytes in combination with FISH using all-chromosome centromeric probe Sari-Minodier et al. (2002); cultured 72 hr, smeared onto slides, stain 5% Giemsa, 2,000 binucleated cells scored/subject, criteria Fenech (2000) blinding not described. | Recruitment and selection not described. Participation rates not reported. Excluded x-ray history during previous 6 mos, use of drugs | Comparison groups were similar for potential confounders | Multivariate regression of genotoxic markers with possible confounders excluding smokers; age and gender were associated but exposure groups were comparable | Exposed n = 31 Referent n = 31 | No obvious bias
Burgaz et al. (2001) (Turkey) Anatomy/pathology departments in hospital & university | Stationary area measurements; number of samples and duration not reported | Nasal respiratory mucosal cells; collected using endocervical brush, cells smeared onto previously coded slides, stain Feulgen’s reaction plus Fast Green, MN, 3,000 cells/ subject counted, scoring criteria Sarto et al. (1987) and Tolbert et al. (1992) | Recruitment and selection not described. Referents worked in same hospital & university | Higher proportion of females in exposed (referent was only male), slightly older individuals, and smokers (and heavy smokers) in referent. Analyses stratified by smoking. Stated that referents had no occupational exposure to genotoxic agents. | Comparison of means using nonparametric methods, two-tailed tests, stratified by smoking; correlation using Spearman’s test | Exposed n = 23, Referent n = 25 | Possible bias to null because of age in referent
Burgaz et al. (2002) (Turkey) Anatomy/pathology departments in hospital & university; Possible overlap with Burgaz et al. (2001) | Stationary area measurements; number of samples and duration not reported | Buccal mucosal cells; cells collected with wooden spatula, smeared onto slides, stain Feulgen’s reaction plus Fast Green, MN, 3,000 cells/ subject counted, coded slides, scoring criteria Sarto et al. (1987) and Tolbert et al. (1992) | Recruitment and selection not described. Referents worked in same hospital & university | Higher proportion of females (referent was only male), and smokers in referent. Age comparable. Stated that referents had no occupational exposure to genotoxic agents; | Comparison of means using nonparametric methods (Mann-Whitney test), two-tailed tests, correlation using Spearman’s test Multifactorial ANOVA adjusting for smoking, exposure and gender and age | Exposed n = 28, Referent n = 18 | No obvious bias
Costa et al. (2008) (Portugal) Hospital pathology laboratories (n = 4) (prevalence) | Samples in breathing zone, NIOSH method #3500. Sampling duration, sample number were not given. 8-hr TWA calculated for each worker | Peripheral lymphocytes; blood samples collected 10–11 am; processed immediately; Scored blind to exposure status; Comet assay, parameter: tail length, alkaline conditions (pH = 13), Singh et al. (1988) lysis 1 hr, 20 min electrophoresis, 100 cells/ subject, image analysis software; Cytokinesis-blocked MN test, Teixeira et al. (2004); culture incubation 72 hr; samples applied by smears to slides, stain 4% Giemsa; scored 1,000 binucleated cells/ subject, scored blind by one reader, criteria Caria et al. (1995); SCE/cell, 50 2nd division metaphases scored by one observer, Scored blind to exposure status | Selection & recruitment of exposed and referent not described. Participation rates not reported. Unexposed worked in administrative offices in hospitals in proximity to pathology labs | Exposed matched to unexposed by age, gender, lifestyle and smoking habits; unexposed worked in same area in administrative offices Demographic information provided | Analyses by one-way ANOVA and Student’s t-test | Exposed n = 30; Referent n = 30 | No obvious bias
Costa et al. (2011) (Portugal) Hospital pathology laboratories (n = 5) (prevalence) | Samples in breathing zone, NIOSH method #3500. Sampling duration, sample number was not given. 8-hr TWA calculated for each worker | Peripheral lymphocytes; blood samples collected 10–11 am; processed immediately; scored blind to exposure status; comet assay, parameter: tail length and % tail DNA; alkaline conditions, Singh et al. (1988) 100 cells/ subject, image analysis software; Cytokinesis-blocked MN test Teixeira et al. (2004); culture incubation 72 hr; samples applied by smears to slides, stain 4% Giemsa; scored 1,000 binucleated cells/ subject, scored blind by one reader, criteria Fenech (2007) | Selection & recruitment of exposed and referent not described. Participation rates not reported. Excluded exposed with <1 year employment. Unexposed worked in administrative offices in hospitals in proximity to pathology labs. | Exposed matched to unexposed by age, gender, and smoking habits. Demographic information provided | Comet assay: normal distribution, analyses by one-way ANOVA and Student’s t-test MN: not normal distribution, used nonparametric tests, Mann-Whitney U test and KruskalWallis test | Exposed n = 48; Referent n = 50 | No obvious bias.
Costa et al. (2013) (Portugal) Anatomy/pathology lab workers | # samples and duration not reported. Air sampling in breathing zone. Calculated 8-hr TWA for each subject; NIOSH method # 3500 | Peripheral blood samples collected between 10–11 am. Samples processed and assays conducted blinded. Cytokinesis-blocked MN test Teixeira et al. (2004). 1,000 cells analyzed/subject, MN per 1,000 binucleated cells, scored blindly by one reader, criteria Fenech (2007). SCE, scored 50 M2 metaphases/subject by one reader T-Cell Receptor mutation assay in mononuclear leukocytes, # events in mutation cell window (CD3-CD4+ cells) divided by total number of events for CD4+ cells | Included workers with at least 1-year employment in 4 hospital pathology anatomy labs; referent worked in administrative offices in same area & no occupational exposure history to formaldehyde | Similar in gender distribution, age, BMI, and smoking habit Demographic information provided | Difference in means, Student’s t-test; tested for normal distribution multivariate analysis adjusted for age, gender, and smoking | Exposed n = 35; referent n = 35 | No obvious bias
Costa et al. (2015) (Portugal) Anatomy/pathology laboratories | Samples in breathing zone for periods during formaldehyde-related tasks, NIOSH method #3500. Sampling duration, sample number was not given. 8-hr TWA calculated for each worker | Peripheral blood samples collected between 10–11 am. Samples processed and analyzed blinded. Chromosome aberrations (structural and numerical), duplicates cultured 51 hrs cited Roma-Torres et al. (2006), 4% Giemsa stain; coded slides; scored 100 metaphases per person, 1,250× magnification; CTAs & CSAs according to Savage (1976); gaps not included. Comet assay: alkaline conditions according to Singh et al. (1988); Scored blind 100 cells/donor from two gels; % DNA in comet tail. | Included workers with at least 1-year employment in 4 hospital pathology anatomy labs; referent worked in administrative offices in same area & no occupational exposure history to formaldehyde; exclusions cancer/tumor history, radiation therapy or chemotherapy treatments, last year surgery with anesthesia and blood transfusions. | Similar distributions by exposure group for age, gender, and smoking. Evaluated possible confounding by other measures (diet) and found confounding by fruit consumption for frequency of multiaberrant cells and %tDNA. | Exposed compared to unexposed using Student’s t test for ln % tDNA or Mann-Whitney U-test for CA measures; linear regression of ln %tDNA; negative binomial regression for untransformed total-CAs, CSAs, CTAs, gaps, aneuploidies, & aberrant cells; Poisson regression for untransformed multiaberrant cells. Models adjusted for age, gender and smoking plus actual confounders for specific parameters. Analyzed effect modification by genotype (homozygous variant plus heterozygous) compared to homozygous wildtype, genotype frequency compared by Pearson’s chi-square test | Exposed = 84; Unexposed = 87 | No obvious bias
Costa et al. (2019) (Portugal) Anatomy/pathology laboratories | Samples in breathing zone for periods during formaldehyde-related tasks and at other sites “considered relevant”, NIOSH method #3500. Sampling duration and number were not given. 8-hr TWA calculated for each worker | Peripheral blood samples collected and processed and assays conducted blinded. Exfoliated cells were collected for each cheek separately. Cytokinesis-blocked MN test, Costa et al. (2008); culture incubation 72 hr; samples applied by smears to slides, stain 4% Giemsa; scored 1,000 binucleated cells/ subject, scored blind by one reader, criteria defined by Fenech (2007) Buccal MN cytome assay. Scored blind by same reader, 2,000 differentiated cells scored for frequency of MN, nuclear buds and nucleoplasmic bridges according to Tolbert et al. (1992); Thomas et al. (2009). SCE/cell, 50 2^nd^ division metaphases scored by one observer, Scored blind to exposure status. T-Cell Receptor mutation assay in mononuclear leukocytes, flow cytometry, minimum of 2.5 × 10^5^ lymphocyte-gated events were acquired, # events in mutation cell window (CD3-CD4+ cells) divided by total number of events for CD4+ cells | This study analyzed additional endpoints using blood and buccal cell samples collected in Costa et al. (2015). Selection & recruitment of exposed and referent not described. Participation rates not reported. Included workers with at least 1-year employment in 9 hospital pathology anatomy labs; referent worked in administrative offices in same area & no occupational exposure history to formaldehyde. | Similar distributions by exposure group for age, gender, and smoking. Exposed smokers smoked less than unexposed smokers (11 vs. 15 pack-years). Evaluated possible confounding by other measures (diet) and found confounding by fruit consumption for frequency of multiaberrant cells and %tDNA. The association of exposure with possible confounders was examined using linear regression. Dietary habits were reported to be parameter-specific actual confounders for white blood cell counts. | Sample size varied by endpoint because of “sample limitation and/or technical losses,” although missingness likely not associated with exposure. Data were log transformed to approximate normal distribuion for TCR-Mf and Mann-Whitney U test applied to MN in lymphocytes and buccal cells and nuclear buds in buccal cells. Associations (mean ratio (MR), 95% CI) with SCE, MNB, BNbud and log TCR- Mf were assessed using Poison regression. Untransformed MNL also were modeled using negative binomial regression. Models adjusted for age, gender, smoking habits and dietary habits.; Effect modification by genotype analyzed using Mann-Whitney U test for specific polymorphisms in CYP2E1, GSTM1, GSTT1, GSTP1, SRCC1, PARP1, MUTYH, RAD51 BRIP1 and FANCA. | MNL; Exposed = 84; Unexposed = 87; SCE/cell; Exposed = 84; Unexposed = 87; MNB Exposed = 63; Unexposed = 69; BNbud; Exposed = 63; Unexposed = 69; TCR-Mf; Exposed = 61; Unexposed = 64 | No obvious bias
Fleig et al. (1982) (Germany) Formaldehyde manufacturing | Personal sampling, 8-hr shift, number of measurements or people with monitors not reported. Measurements were not reported. Provided categories of maximum exposure as % of MAK value for 25%, 60%, and 100% of MAK for two periods (before and after 1971) | Chromosome aberrations, peripheral blood lymphocytes cultured 70–72 hrs, 10% Giemsa stain; coded slides. Presented aberrant cells/individual both including gaps and excluding gaps | Recruitment and selection of participants not described. Referent group from administrative or office staff at same site with no formaldehyde exposure | Referent matched to exposed by age and gender; stated smoking not associated with CA (data not reported) | Fisher-Yates exact test | Exposed n = 15, referent n = 15 | Cell incubation period 72 hrs
Gomaa et al. (2012) (Egypt) Pathology, histology and anatomy laboratories at a university | No formaldehyde measurements | Chromosome aberrations (structural and numerical) cited Verma (1998), peripheral blood lymphocytes cultured 72 hrs, 5% Giemsa stain; blinding not described; scored total CA and types, analyzed 50–100 metaphases per subject.; Comet assay, alkaline conditions according to Singh et al. (1988); tail length & tail moment; blinding not described; analyzed 50 cells per subject. | Recruitment and selection of participants not described. Referent group described to be unexposed | Age comparable between exposed and referent; data analysis by gender; no evaluation of smoking | Difference in mean values between exposed and referent, Student’s t-test | Exposed n = 30, referent n = 15 | Cell incubation period 72 hrs; blinding not described; no evaluation of smoking
Hayes et al. (1997) (USA) Panel study, 9 wks embalming course; Related to Suruda et al. (1993) | Personal sampling; cumulative exposure estimated using sampling data and time-activity data; continuous area samples at head height over embalming tables for short-term peak concentrations; monitored for other compounds: glutaraldehyde, methanol, isopropyl alcohol, and phenol | Blood samples collected in morning before 1^st^ class and after 9 wks; analysis blinded to exposure status; O^6^- alkylguanine DNA alkyl-transferase activity in peripheral blood lymphocytes (according to Klein and Oesch, 1990), expressed as pmol AGT/mg protein (LOD 0.006 pmol AGT/mg protein), blind to period of sample (before or after) | Recruited volunteers prior to beginning of course; reported loss to follow-up. | 15 students had some prior embalming experience during lifetime; exposure to other chemicals below LOD or very low; confounding not likely | Change in individual; Individual data pre- and postcourse AGT activity in peripheral blood lymphocytes depicted in graphs by embalming experience during previous 90 days (yes/no), ANOVA adjusting for age, sex, and smoking. | N = 29 | No obvious bias, small sample size
He et al. (1998) (China) Prevalence Anatomy students | Breathing-zone samples during dissection; number, duration of sampling not described | Blood collection not described. Assays used whole blood. Cytokinesis-blocked MN assay, cultured 72 hr, cells processing (Fenech and Morley, 1985), blinding not described (scored 1,000 cells per individual), CA analyzed 100 metaphases, modified fluorescence-plus-Giemsa stain; SCE analyzed 50 metaphases, Giemsa stain, Blinding not described | Recruitment and selection details not described. Demographic data comparing exposed and referent groups were not provided. | All nonsmokers, age and sex similar (data not reported) | Analytic method not described | Exposed n = 13; Referent n = 10; (# in table reported as 13) | Deficiencies and inconsistency in reporting, small sample numbers.
Jakab et al. (2010) (Hungary) Hospital and university pathology department | Area samples, records of measurements within 1–3 years of study 8-hr TWA determined | Venous blood collection, timing not stated, peripheral blood lymphocytes HPRT gene mutations, unscheduled DNA synthesis, CA and SCE whole blood samples, cultures incubated 50 (CA) and 72 (SCE) hours; CA stain 5% Giemsa, SCE fluorescence plus Giemsa; analyses blinded, for CA scored 100 metaphases/subject. Scored total CA and types, SCE and high frequency SCE, total premature centromere division (PCD) and mitoses with >3 chromosomes with PCD | Recruitment and selection of participants not described. Participation rates not reported. Referent group from healthservice staff in same hospitals | Provided data on demographic characteristics; Age comparable, Formaldehyde only group had higher proportion of smokers, more cigarettes/d and higher proportion drinkers. Solvents were ethyl alcohol, acetone, and xylene | Exposure groups compared, student’s t-test SCE stratified by smoking, CA frequency analyses not stratified | HCHO alone N = 21; HCHO and solvents N = 16; Referent N = 37 | Possible confounding by smoking on CA association not assessed.; Direction: potential overestimation
Jiang et al. (2010) (China) Woodworkers (prevalence study) | Personal samples in breathing zone; 3–5 workers from each job title, 5 referent workers; 8 hr samples; calculated 8-hr TWA | Blood lymphocytes; blinded analysis; comet assay (DNA strand breaks), lymphocytes isolated within 2 hr after blood draw, alkaline conditions, (Singh et al., 1988); slides desiccated, shipped to Beijing, >100 cells/ subject, image analysis software. MN: cytokinesis-block micronucleus assay (chromosome damage), scoring criteria (Fenech et al., 2003) 1,000 binucleated lymphocytes/subject | Selection & recruitment of exposed and referent not described. Participation rates not reported. 263 male workers all Han Chinese; 151 exposed from 2 plywood industries; 112 referents from a machine manufacturing plant in same town | Excluded subjects with recent exposure to known mutagenic agents (x-ray) chronic conditions (autoimmune disease), recent antibiotic use. Structured questionnaire collected info on smoking, alcohol, medical conditions, occupational history & house redecoration in last year. Evaluated mean age and frequency of smoking and alcohol by exposure level. | Ln-transformed Olive TM and CBMN frequency ANOVA differences by exposure group; t-test for differences in means. ANCOVA differences by years of exposure among exposed adjusted for age, formaldehyde concentration, smoking and alcohol. | Referent N = 112; Exposed N = 151 | No obvious bias
Kitaeva et al. (1996) (Russia) Translation Formaldehyde production and anatomy lab workers | Exposure definition by job task, no formaldehyde measurements | MN assay in buccal mucosal cells, blinding not described, cell collection using swab, smeared onto slides, stain Feulgen and light green, analyzed 2,000 cell/ subject. CA in peripheral blood (blood from finger), reported % metaphases with aberrations after 72-hrs culture; # metaphases at 72 hrs cultivation was low (148), observed in only 8 exposed workers | Recruitment and selection not described. Referent group not defined clearly. | Referents 10 years younger than exposed; Stated that age and smoking were not related to MN or CA frequency, gender not related among unexposed, Data not shown. | Analysis using Student method with Freeman-Tukey transformation and results were not clearly presented | Female Exposed n = 8; Female Referent n = 7; Students n = 12 | Small numbers, reporting deficiencies for details of study design and results, difficult to evaluate
Kurttio et al. (1993) (Finland) Wood plywood/veneer manufacture | No formaldehyde measurements; exposure defined by task; 5 out of 15 exposed, considered to be exposed to formaldehyde; referent selected from same town employed at municipal energy plant, a loading company, or a health care center | Venous blood samples cultured all on same day; cultured for 48 hr according to (Jantunen et al., 1986); slides coded; analyzed 100 metaphases per subject | Selection of exposed and referents not described; referents were employed in other industries (potential for dis-similarities) | All male, matched on age, data analysis excluded 1 smoker | Structural aberrations, mean # per cell by exposure, Mann-Whitney U-test (2-tailed) | Exposed n = 15; Referent n = 15 | 5 out of 15 considered exposed to formaldehyde; no formaldehyde-specific data analysis; Not informative
Ladeira et al. (2011) (Portugal) Histopathology labs in 6 hospitals | Personal air sampling, 6–8 hrs, estimated 8-hr TWA (NIOSH method 2541) Ceiling values for each task | Cell collection between 10 am and noon. Samples coded and analyzed blinded. Peripheral blood lymphocytes, cytokinesis-block micronucleus cytome assay, fresh samples, cultured for 72 hr, applied to slides with cytocentrifuge, May-Grunwald-Giemsa, 1,000 binucleated cells scored/subject by 2 readers; buccal mucosa cells, collection using endobrush, smeared onto slides, stain Feulgen, 2,000 cells scored/subject, 2 readers | Recruitment and selection not described. Participation rates not reported. Excluded history of cancer, radio or chemotherapy, use of therapeutic drugs, exposure to diagnostic x-rays in the past 6 mos, intake of vitamins or other supplements like folic acid (no one was excluded) | Exposed were older, with lower proportion of drinkers and smokers | Comparisons by exposure group; binary logistic regression and Mann-Whitney test Stratified by categories of age, gender and smoking | Exposed n = 56, referent n = 85 | No obvious bias
Lan et al. (2015) (China) Formaldehyde-melamine resin production or use; (related study; related study; Zhang et al. (2010); Bassig et al. (2016)) | Personal monitors for 3 d over entire shift within a 3-wk period. Formaldehyde concentration: 8-hr TWA Exposed; Median: 1.38 ppm (1.7 mg/m^3^) 10th & 90th percentile: 0.78, 2.61 ppm 0.96, 3.2 mg/m^3^); Referent; 0.026 ppm (0.032 mg/m^3^) 10th & 90th percentile: 0.015, 0.026 ppm (0.019, 0.032 mg/m^3^); LOD: 0.012 ppm | Postshift and overnight peripheral blood samples. Metaphase spreads from colony forming unit granulocyte macrophage (CFU-GM) cultured for 14 d; chromosome-wide aneuploidy analysis using OctoChrome FISH; scored minimum 150 cells/ subject; analysis blinded to exposure. | Analyzed aneuploidy among subset with scorable metaphases, high formaldehyde among exposed and existence of comparable referents. Participation rates exposed 92%, referent 95%. Referent from 3 workplaces in same geographic region as exposed, engaged in manufacturing with similar demographic and SES; excluded history of cancer, chemotherapy, and radiotherapy, previous occupations with exposure to benzene, butadiene, styrene, and/or ionizing radiation. | Referents frequency-matched by age (5 year) and gender Personal sampling of volatile organic compounds; concentrations at background, urinary benzene at background and comparable between groups | Analyzed using negative binomial regression controlling for age and gender. Also evaluated potential confounding from current smoking and alcohol use, recent infections, current medication use, and body mass index (Supplemental tables in (Lan et al., 2015)). | Exposed n = 29; Referent n = 23 | No obvious bias
Lazutka et al. (1999) (Lithuania) Carpet and plastic manufacturing Prevalence study | Industrial hygiene area measurements reported by plant; carpet plant, formaldehyde 0.3–1.2 mg/m^3^, styrene 0.13–1.4 mg/m^3^, phenol 0.3 mg/m^3^; plasticware plant, formaldehyde 0.5–0.9 mg/m^3^, styrene 4.4–6.2 mg/m^3^, phenol 0.5–0.75 mg/m^3^ | Peripheral blood samples; chromosome aberrations, cells cultured 72 hr, differential staining fluorescence–plus-Giemsa, CA scored on coded slides, >100 first mitotic division cells per subject. | Recruitment and selection not described. Participation rates not reported.; Source population for nonexposed referents not described | Nonexposed were “approximately” matched to exposed by age; males and females, smokers and nonsmokers included; demographic information provided; unable to distinguish between formaldehyde and styrene | ANOVA including variable for exposure and age, no adjustment for smoking or gender; CA data transformed using average square root transformation | Carpet plant, exposed 38 male, 41 female; unexposed 64 male, 26 female; Plastic plant, exposed 34 male, 63 female; unexposed 64 males, 26 females | Cell incubation period 72 hrs; unable to distinguish between formaldehyde and styrene effects; Direction: potentially overestimated
Lin et al. (2013) (China) Woodworkers (prevalence study) 2009 (cross-shift) 2011 | Prevalence: Area samples (2 badges in each of 5 workplaces with differing tasks), 8-hr samples on 2 d. Change over work-shift: badges in breathing zone of 2–4 representative workers conducting different job types (8-hour samples). Referent group exposed, mean 0.13 mg/m^3^ (0.019–0.252) | Blood lymphocytes; blinded analysis; comet assay (DNA strand breaks), alkaline conditions (pH = 13) (Olive and Banath, 2006), lysis 2-hr for N = 178 & over-night for N = 62, 50 lymphocytes/sample, image analysis software; cytokinesis-block micronucleus assay, Fenech (1993) analyzed 1,000 binucleated cells/ subject, scoring criteria Fenech (1993), Fenech et al. (2003); Zhitkovich and Costa’s KCI-SDS assay (DNA-protein crosslinks) | Selection & recruitment of exposed and referent not described. Participation rates not reported. Exposed and referent from same factory. | Excluded subjects with exposure to known mutagenic agents in previous 3 months (radiotherapy & chemotherapy). Structured questionnaire collected info on smoking, alcohol, medical conditions, occupational history, and house redecoration in last year. | Natural logtransformed olive TM. Prevalence: ANOVA differences by exposure group (control, low and high), adjusting for age, sex, smoking, alcohol, # work years) Regression for trend across exposure level adjusting same as above; Poisson regression for MN frequencies, linear regression for Ln(OTM) Across-shift: Paired Wilcoxon text (MN freq) or paired t-test (OTM or DPX); regression models for trend with exposure levels | Referent N = 82; Low N = 58; High N = 38 | Referent group with significant formaldehyde exposure, potential bias toward null.
Marcon et al. (2014) (Italy) Population living in proximity to chipboard plants | Modeled outdoor formaldehyde concentrations at residential address based on data from 62 monitoring sites in district; four 1-wk sampling periods (2 each in warm and cold seasons); calculated annual average concentration of formaldehyde and NO_2_; estimated at each address using ordinary Kriging; formaldehyde 2.5 ± 0.3 mg/m^3^, NO_2_ 16.0 ± 3.5 mg/m^3^, | Epithelial mucosal cells using cytology brush; comet assay, alkaline conditions, 50 cells per subject; MN 2,000 cells per subject, according to Tolbert et al. (1991) | Random sample of participants in previous survey (93% of population in Viadana District) with children under 12 years, Italian primary language, and address information; invited stratified random sample in 3 strata of distance from wood factories (656 remaining in district since 2006 of 750), participation 63%, participation was not higher in residents closest to wood factories; higher proportion of nonparticipants were of foreign nationality and had smoking parents | No adjustment for indoor formaldehyde concentrations; co-exposure with NO_2_ | Linear regression for tail length, tail intensity, tail moment and binucleated cells; negative binomial regression for micronuclei and nuclear buds; models adjusted for children’s sex, age, nationality, parents’ education, parents’ smoking, exposure to tobacco smoking at home, time with windows open, traffic near home, orthodontic appliance, condition of teeth, person who collected cell sample | N = 413; Analysis included only complete datasets for comet assay, n = 310 and MN n = 374 | Potential exposure misclassification; no obvious bias; No indoor formaldehyde exposure measure; Not informative
Musak et al. (2013) (Slovakia) Prevalence study Pathologists | Air monitoring once per year (no details provided) | Chromosomal aberration, peripheral blood lymphocytes, blinded analysis, cultured 48 hr, 100 mitoses scored/subject, 2 scorers | Recruitment and selection of participants not described. Participation rates not reported. Exposed and referent all employed in hospitals | Exposed and referent comparable for age, gender; % smokers slightly higher in exposed; analyses adjusted for age, gender, job type, and smoking | Adjusted odds ratios, Binary logistic regression controlling for age, gender, job type, and smoking | Exposed N = 105; Referent N = 250 | No obvious bias
Orsiere et al. (2006) (France) Hospital pathology labs (prevalence) | Personal sampling near breathing zone; Short-term: 15 minutes, Long-term 8 hrs during typical work day. | Peripheral lymphocytes, blood samples taken preshift and postshift; processed within 6 hr, assays conducted blinded. Chemi-luminescence microplate assay; cytokinesis-blocked micronucleus assay Sari-Minodier et al. (2002); cultured 72 hr, smears on slides, stain 5% Giemsa, scoring criteria (Fenech, 2000); 1,000 binucleated cells/ subject; FISH with a pan-centromeric DNA probe, same operator scored exposed and referent blinded | Selection & recruitment of exposed and referent not described, however subgroups selected randomly. Exposed and referent worked in same institution. | Groups similar for gender, age, % smokers. No exposure to other genotoxic substances. Excluded history of radiotherapy or chemotherapy and use of therapeutic drugs that were known mutagens or reproductive toxicants | Differences by group analyzed using nonparametric Mann-Whitney U-test; median DNA repair across shift analyzed using Wilcoxon W-rank sum test. Analyzed binucleated micronucleated cell rate (BMCR), and MN measures using multivariate regression adjusting for smoking, drinking, age, and gender. | Exposed n = 59; referent n = 37; Subgroups Exposed n = 18; referent n = 18 | No obvious bias.
Pala et al. (2008) (Italy) Research institute lab (prevalence) | Personal samples, one 8-hr shift; 75% exposed to < 0.026 mg/m^3^. | Peripheral blood samples collected at same time at end of day; processed within 20 hr; analysis blind to exposure. CA, harvested after 48 hr, 100 metaphases/subject SCE, cultures harvested at 72 hr, analysis of 30 second-division cells/ subject; MN: modified cytokinesis-blocked method, Fenech and Morley (1986); 72 hr incubation, stain 3% Giemsa, 2,000 cells/ subject | Selection & recruitment of exposed and referent not described. Participation rates not reported. | Statistical models adjusted for gender, age, and smoking | Multivariate regression models adjusting for gender, age, and smoking; Poisson model for CA and MN, SCE log-normal random effects model, comparisons were low and high exposure groups, below and above 26 µg/m^3^ | N = 36 | No obvious bias; only 9 exposed above 0.026 mg/m^3^.
Peteffi et al. (2015) (Brazil) Furniture manufacturing | Monitoring in 7 sections in facility; referent monitoring in 5 areas of university; breathing zone 8-hr samples collected on same day as biological samples. Urine samples collected at end of work day on 5^th^ day of work; correlation of formaldehyde concentration in air with urinary formic acid concentration, r = 0.626, p <0.001 | Peripheral blood processed within 4 hr. comet assay, alkaline conditions according to Tice et al. (2000); silver nitrate staining according to Nadin et al. (2001); 100 cells/person read by two independent observers (50 cells each). Blinding not stated, classified by visual scoring according to Anderson et al. (1994); 5 categories based on tail migration (0–IV) and frequency of damaged cells (sum of I–IV), damage index (Pitarque et al., 1999) Oral mucosa samples (scraped with endocervical brush), micronucleus test, DNA-specific Feulgen staining and counterstaining with Fast Green according to Tolbert et al. (1992); analyzed 2,000 cells/person by 2 independent observers (1,000 ea) | 46 workers in furniture manufacturing facility and unexposed group recruited from employees and students of local university with no history of occupational exposure to potentially genotoxic agents or substances metabolized to formic acid | Exposed and referent had comparable distributions for age, smoking, and alcohol; differed by gender Exposed 56.5% male, referent 33.3% male; no association of any biomarkers with gender (data not shown) | Nonparametric tests used because data were not normally distributed. Exposed and referent compared using Mann-Whitney test; | Exposed n = 46, referent n = 45 | No obvious bias
Santovito et al. (2014) (Italy) Hospital nurses | All exposed used protective equipment; no formaldehyde measurements, intensity and frequency likely highly variable | Peripheral blood samples, coded, processed within 2 hr after collection. Cultures incubated for 48 hr for CA and 72 hr for SCE; CA slides stained with 5% Giemsa, scored 200 metaphases per subject, gaps not scored as CA; SCE 50 metaphases scored per subject | 20 female nurses from 2 analogous departments in 2 hospitals; 20 referents from administrative departments of same hospital; all nonsmokers and did not consume alcohol | Accounted for sex, age, smoking, and alcohol in design; referents from same hospitals Nurses exposed to other substances | Mean frequencies compared, Wilcoxon test; regression analysis, association of age and exposure duration on CA and SCE | Exposed n = 20; Referent n = 20 | Potential for large degree of exposure misclassification and variation in intensity of exposure; bias toward null; small sample size
Santovito et al. (2011) (Italy) Pathology wards | Personal sampling near breathing zone, 8-hr duration | Venous blood sample collected at end of shift, samples coded and processed within 4 hr, same day concentration sampling conducted, cultured 48 hrs; CA 5% Giemsa stain; scored 100 metaphases/subject | Recruitment and selection of participants not described; participation rates not reported. | All nonsmokers, nondrinkers, no drug use 1 year prior; no information on other exposures (acetone, ethyl alcohol, xylene) | Mean % of cells with aberrations and frequencies of aberrations per cell compared using Mann-Whitney U test, 2-tailed. Generalized linear models (Poisson distribution) adjusting for age, gender, polymorphisms, Cubic spline regression of mean % of cells with aberrations and frequencies of aberrations per cell with number years exposed and age | Exposed n = 20; Referent n = 16 | No obvious bias Small sample size
Schlink et al. (1999) (Germany) Anatomy students | Personal sampling near breathing zone once per week, sampling period not reported. formaldehyde exposed, Mean ± SD, 0.2 ± 0.05 mg/m^3^, 0.14–0.3 mg/m^3^ | Blood samples collected before 1^st^ class and after days 50 and 111; O^6^-alkylguanine DNA alkyl-transferase activity in peripheral blood lymphocytes (modification of Klein and Oesch (1990), expressed as fmol MGMT/10^6^ cells (LOD 1 fmol MGMT/10^6^ cells), blind to period of sample (before or after) | Recruitment and participation of students were not described. 41 students from 1 university course, 16 students from a different university course, and 10 unexposed students | Considered effects of age, sex, smoking, and alcohol | MGMT activity change compared (U-test, paired data) within categories of sex, smoking, allergy, and alcohol; as well as between groups (Wilcoxon, Mann and Whitney U-test) | Exposed N = 41; Referent N = 10 | No obvious bias, small sample size
Shaham et al. (1997) (Israel) anatomy/pathology departments (prevalence); also reported in Shaham et al. (1996) | Personal and “field” samples, duration 15 min, multiple times during work day (# not reported). | Peripheral lymphocytes; DPX, K-SDS method; double blinded. SCE at 72 hrs, mean of 30 cells/individual, blinding not described | Selection & recruitment of exposed and referent not described. Participation rates not reported. Referent group worked at same institution. | Exposed and referent matched by age (matching protocol not described). No exposure to other mutagens or substances known to cause DPX in either exposed or referent. | Analyses by ANOVA adjusting for smoking; difference in means, t-test; linear regression for DPX levels or means SCE per chromosome by years of exposure to formaldehyde | Exposed DPX: N = 12 SCE: N = 13 Referent DPX: N = 8 SCE: N = 20 | Low sample numbers; no obvious bias.
Shaham et al. (2002) (Israel) Hospital pathology labs | Personal and area samples, sampling at different points in work day, sampling duration averaged 15 min | SCE in peripheral lymphocytes, blood samples collected at same time in morning; blinding not described, stain fluorescence plus 5% Giemsa, scored 30–32 cells/ subject | Recruitment and selection of participants not described. Referent group from administrative sections of same hospitals | Authors presented demographic data. Exposed were higher proportion female, European/American, education >12 year, and lower proportion smokers. No exposures to other chemicals linked to SCE. Confounding addressed in analysis | Mean # SCEs per chromosome and proportion of high frequency cells compared between exposed and referent. Difference between means assessed using ANOVA (unbalanced design) adjusting for age, gender, smoking, origin and education years | Exposed n = 90; Referent n = 52 | No obvious bias
Shaham et al. (2003) (Israel) 14 hospital pathology departments (prevalence) | Personal and “field” samples, duration 15 min, multiple times during work day (# not reported). | Peripheral lymphocytes; DPX, same protocol as Shaham et al. (1997); SCE; pantropic p53 | Selection & recruitment of exposed and referent not described. Exposed and referent worked in same institution. | Adjustment for age, sex, smoking, origin, and years of education in analysis. No exposure to other mutagens or substances known to cause DPX in either exposed or referent. | Analyses: comparisons of mean DPX adjusted for sex, smoking, age, origin, and years education. Comparison of mean DPX by low and high formaldehyde levels and by duration of exposure, Mann-Whitney test | Exposed N = 186; Referent n = 213 | No obvious bias.
Souza and Devi (2014) (India) Prevalence study Anatomy Dept (embalming) | No formaldehyde measurements reported. | Total MN/1,000 cells peripheral lymphocytes. Assays conducted blinded. Cytokinesis-blocked micronucleus assay Costa et al. (2008); stain 4% Giemsa, scoring criteria Fenech (2000), 1,000 binucleated cells/ subject. Frequency MN compared by exposure group using Student’s t-test, and by duration of employment using Pearson’s correlation. | Recruitment and selection of participants not described. Participation rates not reported. | Provided characteristics of exposure groups (see Table 1). All male, age comparable, higher prevalence smokers in exposed. Adjustment in analysis. Excluded frequent exposure to x-rays or other radiation, worked in paint or pesticide industries or history of chemotherapy. | Frequency MN compared by exposure group using Student’s t-test, and by duration of employment using Pearson’s correlation. Exposure and smoking evaluated together using two-way ANOVA. | Exposed N = 30; Referent N = 30 | No obvious bias
Speit et al. (2007a) (Germany) Controlled human exposure study | Generation using para-formaldehyde; 10 consecutive d, 5 groups of 3–6 persons in chamber, 4 hr exposures, some exposures masked with ethyl acetate, 3 15-min exercise sessions during exposure; randomized order of concentration, double blinded | MN in buccal mucosal cells–1 wk before start, at time=0, after end of exposure, and 1, 2, and 3 wks after end of exposure; cells collected with metal spatula, smeared onto slides, blinded analysis at end of study by 1 person, stain DAPI/propidium iodide, 2,000 cells/ subject | Excluded severe allergy, skin or airways disease, acute infection, current smoking or within last 3 years, contact lenses or glasses, > 50 g alcohol per day, present use of psychotropic agents, exposure to ionizing radiation, or cytostatic drugs during the last 6 mos | Within person comparison | Post exposure compared to preexposure using Wilcoxon ranked sum test | N = 21 | No obvious bias.
Suruda et al. (1993) (USA) Panel study, 85 d Embalming course | Personal sampling for 121 of 144 embalmings; cumulative exposure estimated using sampling data and time-activity data; Continuous area samples at head height over embalming tables for short-term peak concentrations; monitored for other compounds: glutaraldehyde, methanol, isopropyl alcohol, and phenol | Nasal mucosa cells, oral mucosa cells, blood samples collected in morning before 1^st^ class and after 9 wks; processed on same day, analysis of slides blinded to exposure status; pre- and postslides from each subject stained at same time and read together by one reader, conducted a blinded 10% recount of slides; MN assay buccal and nasal cells Stich et al. (1982), collected with cytopathology brushes, slides prepared with cytocentrifuge, stain Feulgen/Fast Green, 1,500 cell/ subject; MN lymphocytes Fenech and Morley (1985), stain Feulgen 2,000 cells/ subject; SCE 50 s division metaphases scored/subject | Recruited volunteers prior to beginning of course; reported loss to follow-up. Excluded one student with many embalmings in previous 90 d, & 1 students who chewed tobacco during study | 21 students had some prior embalming experience during lifetime; exposure to other chemicals below LOD or very low, confounding not likely | Change in individual; difference in mean pre- and postexposure, matched Student’s t-test (SCE) or Wilcoxon sign-rank test (micronuclei); Change with cumulative exposure spearman’s rank correlation coefficient & linear regression (if residuals were normally distributed) | N = 29 | No obvious bias
Suskov and Sazonova (1982) (USSR) Phenol-formaldehyde resin production | Area samples, # and duration not reported | Cytogenetic analysis in peripheral lymphocytes; Chromosomal aberrations, blinding not described, Buckton and Evans cytogenetic method, 1973 | Recruitment and selection not described. | Average age in exposed 39.1 year, referent 34 year. Matched for gender, smoking, alcohol, and medication (data not shown) | Compared chromosome aberration frequency by exposure group, chi-square | Exposed n = 31; Referent n = 74 | Brief report, minimal detail of methods
Thomson et al. (1984) (Great Britain) Pathology lab | Sampling in breathing zone; 26 samples taken for the duration of the task involving formaldehyde exposure, over 1–3 mos, sample duration not reported, calculated TWA Measured peaks in breathing zone on 1 d for different tasks | CA frequency, stain fluorescence plus Giemsa technique Perry and Wolff (1974), cells harvested 48 hr, slides coded and scored 100 1^st^ division metaphases/subject; SCE frequency, cells harvested 72 hr, 50 cells/ subject; blinding not reported | All exposed worked in same laboratory; characteristics of referent not provided. | Obtained smoking histories | Data analysis not described | Exposed n = 6; referent n = 5 | Reporting of study methods and group characteristics not adequate; low sample numbers
Titenko-Holland et al. (1996) Same subject as Suruda et al. (1993) (USA) Panel study, 90 d Embalming course | See Suruda et al. (1993) Calculated 2 exposure periods:; (1) Lagged 7–10 d before last sampling to account for lag in development of MN; (2) 90-d cumulative | Buccal cells, Scored previously unstained and unanalyzed slides. New method: FISH with a centromeric probe—differentiates between clastogenic vs aneuploidogenic mechanism (total MN, MN− and MN+); <1,500 cells scored for 14 of 35 subjects; scored pre- and postexposure slides at same time, blinded. Frequency calculated by dividing # cells with MN by total # cells counted, multiplying by 1,000. 78% of preexposure slides and 76% of postexposure slides were scorable; 10% of slides were rescored | Subjects with missing MN data were compared to those with complete data by Student’s t-test; comparable for age, smoking, and mean exposure | Change in individual. Exposure to other chemicals below LOD or very low, confounding not likely | Change in total MN, MN− and MN+ frequency (per 1,000 cells) and change in mean MN. Excluded subjects with <500 epithelial cells available for analysis. Difference scores evaluated using Wilcoxon sign-rank test. Association with both formaldehyde exposure metrics via Spearman non-parametric correlation coefficient, two-sided p-values | Complete MN data from buccal mucosa, n = 19 Complete MN data from nasal mucosa, n = 13 | No obvious bias
Vasudeva and Anand (1996) (India) Medical student lab | <1 ppm, no data reported to support assertion | Peripheral blood lymphocytes, frequency of aberrant metaphases; cell culture 72 hr, Giemsa staining, blinding not reported | Recruitment and selection of participants not described. No demographic information provided. | Stated that participants had received no or insignificant radiation treatments (no data reported); exposed and referents matched by age, no other potential confounders evaluated | Data analysis not described | Exposed n = 30; referent n = 30 | Reporting of methods, design and results not adequate to evaluate; cell incubation 72 hr
Viegas et al. (2010) (Portugal) Formaldehyde & resin production, pathology/anatomy lab workers; Also discussed in Viegas et al. (2013) | Personal air sampling, (N = 2 in factory, N = 29 in labs) 6–8 hrs, estimated 8-hr TWA (NIOSH method 2541). Ceiling values for each task | Buccal mucosa Peripheral blood lymphocytes, sample collection between 10 am & noon. Blinded coding and analysis, buccal cell MN cell collection using endobrush, smeared onto slides, Feulgen stain, 2,000 cells scored/subject by 4 observers, scoring criteria Tolbert et al. (1992), peripheral lymphocytes, samples processed within 6 hr, cultured for 72 hr, applied to slides with cytocentrifuge, stain May-Grunwald-Giemsa, 1,000 binucleated cells scored/subject | Recruitment and selection not described. Participation rates not reported. | Presented comparisons for gender, age, and smoking. Difference by gender (higher prevalence males in exposed); genotoxic endpoints were not associated with smoking or gender, and only slightly with age | Correlation evaluated using Pearson or Spearman correlation test depending on distribution | Exposed, Production n = 30, Lab workers n = 50, Referent n = 85 | No obvious bias
Wang et al. (2019) (Shanghai, China) Chemical production | Routine formaldehyde monitoring by factory with sampling site selection using China national standard for hazardous substances air sampling in the workplace. Cumulative dose determined for each worker (C × T). C = geometric mean of concentration for a year at a sampling site, T = years. Serum formaldehyde-albumin adducts (FA-HSA) quantified in fasting venous peripheral blood. Geometric mean range (mg/m^3^):; Exposed: 0.06–0.25; Unexposed: 0.01 | CBMN according to Fenech (2000), Fenech (1993). Blinded analysis. Venous peripheral blood cultured for 44 hr, Cytochalasin-B added to cultures, cells harvested 28 hours later, air dried slides stained with Giemsa, MN detected at 400× with confirmation at 1,000×. 1,000 binucleated cells scored/subject | Recruitment and selection of participants not described; participation rates not reported. 100 male workers exposed to formaldehyde > 1 year through 4 work processes (i.e., production examination, glue spraying, coating and workplace inspection). Demographic information, smoking and alcohol, medical and occupational history (job types and # years) collected by questionnaire. Unexposed group (n = 100 males) from the logistics workshop in same factory age matched (likely frequency matched since rates were different). | Mean age and frequency of smoking and alcohol use were slightly higher in exposed. Work duration was higher in exposed. Age, smoking status and alcohol use were adjusted in statistical models. | MN frequency compared using Poisson regression and frequency ratio (FR) as effect estimate. Exposure was analyzed with quartiles for cumulative dose and FA-HSA concentration. Cumulative dose (mg/m^3^):; 0.01–0.06; 0.06–0.125; 0.125–0.9; 0.9–3.75 | Exposed n = 100; Unexposed n = 100 | No obvious bias
Yager et al. (1986) (USA) Anatomy course, 10 wks | Area samples randomly distributed (N = 13, 1–4/wk); breathing zone samples on 30 individuals at 15 tables (N = 35, 2–8/week), mean sampling duration 18 min | Whole blood cultures; stain fluorescence plus Giemsa technique, Mean SCEs per cell in peripheral lymphocytes; before and after samples coded and randomized together for analysis, scored 80 cells/ subject | Recruitment and selection not described. | All nonsmokers, 7 female | Paired t-test of before and after samples | N = 8 | No obvious bias
Vargová et al. (1992) (Czechoslovakia) Woodworking | 8-hr sampling duration in breathing zone | CA frequency, peripheral lymphocytes, Giemsa staining, cells harvested 48 hr, 100 cells/ subject. Blinding not described.; CA frequency in both exposed and referent was higher than range considered normal | Recruitment and selection of participants not described; participation rates not reported. | Referents were matched to exposed (did not report what matching parameters were), no info on subject characteristics was reported; Authors stated questionnaire data suggested that factors such as smoking and alcohol were different between exposed and referent; analyses were not adjusted. | Exposed and referent compared using student’s t-test and arcsin-sq rt transformation test | Exposed n = 20 (or 25?); Referent n = 19 | Reporting of study methods and group characteristics not adequate; # exposed in text did not match # exposed in table II in the paper. Lack of adjustment for confounding, bias toward null
Ye et al. (2005) (China, 1992) Formaldehyde exposure in factory or indoor air from building materials | Sampling according to NIOSH method; Referent n = 6; Waiters n = 18; Workers n = 36 | MN in nasal mucosa, cell collection using swab, cells smeared onto slide, stain Wright’s, scoring criteria Sarto et al. (1987), per 3,000 cells, blinding not stated, results reexamined by another trained staff. SCE in peripheral lymphocytes, time of sample not stated; stain Giemsa solution, analysis blinded, 30 M_2_ lymphocytes analyzed/subject. | Recruitment and selection not described. Included: nonsmokers, no medicines for 3 wks prior and during study, no x-ray history for 6 mos prior, no drug use; comparison groups were from different sources: industrial exposed, wait staff (indoor air exposed), and unexposed student volunteers | Waiters and workers older than referent, % male 52% in referent, 25% in workers, 61% in wait staff; all Han Chinese; no adjustment for age or gender in analyses. | Analysis using one-way ANOVA and tested for multiple comparisons. Data presented in figures and values estimated from graph by EPA. | Workers n = 18; waiters n = 16; referent n = 23 | Possible bias away from null; expect higher frequency of MN in older individuals. Small sample numbers.
Ying et al. (1997); Ying et al. (1999) (China) Panel study, 8-wk class Anatomy students | NIOSH (1977) method; 3-hr TWA and peaks; sample duration, number and frequency not described | Nasal mucosa cells, oral mucosa cells, blood samples collected before 1^st^ class and after last class; analysis of slides by 1 blinded observer with reexamination by another, nasal and buccal cells collected with swab, smeared onto slides, MN Nasal and Buccal cells, Wright’s stain, scored 4,000 cells/ subject; MN blood lymphocytes, stain 4% Giemsa, scored mean of 2,870–3,167 cells/ subject; MN scoring criteria Sarto et al. (1987), SCE and LTR (Zhao et al., 1994): 30 M_2_ lymphocytes per subject analyzed blind to exposure | Included nonsmokers, students living in dorms, disease-free & no medications prior 3 wks, no x-ray history prior 6 mos | Mean age 18.8 ± 1.0 year, all Han nationality, all lived in dorms, all nonsmokers | Change in individual over time; paired t-tests | N = 25 | No obvious bias, small sample size
Zendehdel et al. (2017) I(ran) Melamine dinnerware manufacturing; Related publication: Zendehdel et al. (2018) | Personal air sampling, NIOSH method 3500, whole shift for each worker. Median time weighted average in three workshops, 0.086 mg/m^3^; range, 0.02–0.22 mg/m^3^; authors state that 2/3 of sample were exposed to < 0.1 mg/m^3^ | Comet assay, alkaline conditions, according to Tice et al. (2000) Blood samples collected same day as air sampling; blinding not described; minimum of 50 randomly selected cells per sample; tail moment and Olive moment | Workers in 3 melamine dinnerware manufacturing workshops (n = 49) and referents matched by age and sex (n = 34) who worked in food industries, # smokers higher in referent (26% versus 16%), >90% male. Recruitment and participation were not described. | Data in Table 1 of paper supported comparability of age, sex, and # smokers in exposed and referent groups. | Normal distribution assessed using Kolmogorov-Smirnov test. Difference in mean tested using Student t-test or Mann-Whitney test | Exposed N = 49; Referent N = 34 | No obvious bias blinding not described;
Zhang et al. (2010) (China) Formaldehyde-melamine resin production or use; Related publications: Gentry et al. (2013); Bassig et al. (2016); (Mundt et al., 2017) Reanalyses | Personal sampling for full shift (>240 min) on 3 working d over 3 wks. Exposed: at least 2 samples per individual; Referent: Sampling in subgroup on 1 d. Evaluated for other known or suspected leukemogens (benzene, phenol, chlorinated solvents), found none. Analysis blinded. | Postshift and overnight peripheral blood samples; analysis blinded to exposure. Metaphase spreads from cultured colony forming unit granulocyte macrophage (CFU-GM); identified loss of chromosome 7 and gain of chromosome 8 using FISH | Participation rates exposed 92%, referent 95%. Referent from 3 workplaces in same geographic region as exposed, engaged in manufacturing with similar demographic and SES; excluded history of cancer, chemotherapy, and radiotherapy; previous occupations with exposure to benzene, butadiene, styrene and/or ionizing radiation. | Referents frequency-matched by age (5 year) and gender | Analyzed using negative binomial regression (exposed compared to unexposed) controlling for age, gender, and smoking; Mundt et al. (2017) presented individual data in graphs for chromosome 7 and chromosome 8, noting smoking status and whether 150 or more cells were evaluated.; Gentry et al. reported that < 150 cells per individual were analyzed for several subjects. Not expected to be different between exposed and unexposed, impact likely to increase variability and attenuate association | High N = 10 Low; N = 12 | Small sample numbers, no obvious bias

1 A separate HERO page was previously used for documentation in prior drafts of this assessment: (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/31). This page included highly variable screening documentation applied as systematic review methods were evolving within the IRIS Program in parallel with development of the draft formaldehyde assessment. The current HERO page (https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/4051) consolidates and refines those search and screening tags into a structure that is more transparent, user-friendly, and consistent with current practice. The total number of studies is lower in the current HERO page. In addition to improvements to HERO (e.g., duplicate removal), the older page includes studies not identified as part of the current systematic reviews; for example, the older page documents the cited references from prior formaldehyde assessments (e.g., the draft 2010 IRIS assessment), including background studies not used in the current assessment.

2 While one study used a sprayer in a heated vessel to generate formaldehyde from a formalin solution containing a known concentration of methanol (Kamata et al., 1997), presumably resulting in the release of formaldehyde and methanol in proportions that would be conserved from liquid to gas (i.e., allowing air methanol levels to be relatively accurately estimated based on air formaldehyde levels), the remaining formalin studies generally evaporated formalin from solution. Notably, the liquid:air partitioning of methanol and formaldehyde is influenced by the proportions of these agents in aqueous solutions (Albert et al., 2000). Thus, as chamber methanol levels were not analytically measured in the other identified studies, a methanol control group may not eliminate uncertainty. Unfortunately, a calculation for estimating methanol levels released (e.g., by evaporation) from formalin solutions at different levels of inhaled formaldehyde was not identified.