# APPENDIX A BACKGROUND INFORMATION SUPPLEMENT

Appendix A introduces potentially useful context for this assessment. These summaries do not provide comprehensive descriptions of the available information on these topics and are not intended for use in decision purposes. Readers are encouraged to refer to source materials cited below, contemporary publications on these topics, and specific assessments on these topic areas.

## A.1 CHEMICAL PROPERTIES

Formaldehyde (CASRN 50-00-0) is the first of the series of aliphatic aldehydes and is a gas at room temperature. Its molecular structure is depicted in Figure A-1. It is noted for its reactivity and versatility as a chemical intermediate. It readily undergoes polymerization, is highly flammable, and can form explosive mixtures with air. It decomposes at temperatures above 150°C (IPCS, 2002).

Figure A-1 Chemical structure of formaldehyde

At room temperature, pure formaldehyde is a colorless gas with a strong, pungent, suffocating, and highly irritating odor (NLM, 2019). Formaldehyde is readily soluble in water, alcohols, ether, and other polar solvents (IPCS, 2002). A synopsis of its physicochemical properties is given in Table A-1.

Table A-1 Physicochemical properties of formaldehyde

Name | Formaldehyde
International Union for Pure and Applied Chemistry name | Formaldehyde
Synonyms | Formic aldehyde; Methanal; Methyl aldehyde Methylene oxide; Oxomethane; Oxymethylene
Chemical Abstracts Service Index name | Formaldehyde
Chemical Abstracts Service Registry Number | 50-00-0
Formula | HCHO
Molecular weight | 30.03
Density | Gas: 1.067 (air = 1); Liquid: 0.815 g/mL at −20°C
Vapor pressure | 3,883 mm Hg at 25°C
Log K_ow_ | −0.75 to 0.35
Henry’s law constant | 3.4 × 10^−7^ atm-m^3^/mol at 25°C; 2.2 × 10^−2^ Pa-m^3^/mol at 25°C
Conversion factors (25°C, 760 mm Hg) | 1 ppm = 1.23 mg/m^3^ (v/v); 1 mg/m^3^ = 0.81 ppm (v/v)
Boiling point | −19.5°C at 760 mm Hg
Melting point | −92°C
Flash point | 60°C; 83°C, closed cup for 37%, methanol-free aqueous solution;; 50°C closed cup for 37% aqueous solution with 15% methanol
Explosive limits | 73% upper; 7% lower by volume in air
Autoignition temperature | 300°C
Solubility | Very soluble in water; soluble in alcohols, ether, acetone, benzene
Reactivity | Reacts with alkalis, acids, and oxidizers

Sources: Walker (1975); IPCS (2002); Gerberich and Seaman (2013); ATSDR (1999); ACGIH (2001).

## A.2 PRODUCTION, SOURCES, AND USES OF FORMALDEHYDE

Formaldehyde has both commercial and industrial uses. Formaldehyde has been produced commercially since the early 1900s and, in recent years, has been ranked in the top 25 highest volume chemicals produced in the U.S. (NTP, 2010; ATSDR, 1999). Based on EPA’s Chemical Data Reporting (CDR) the national production volume for formaldehyde was 3.9 billion pounds/year in 2011 and between 1 and 5 billion pounds/year for the years 2012 through 2015 (https://chemview.epa.gov/chemview/#).

Approximately 55% of the consumption of formaldehyde is in the production of industrial resins (NTP, 2010). Formaldehyde is a chemical intermediate used in the production of some plywood adhesives, abrasive materials, insulation, foundry binders, brake linings made from phenolic resins, surface coatings, molding compounds, laminates, wood adhesives made from melamine resins, phenolic thermosetting, resin curing agents, explosives made from hexamethylenetetramine, urethanes, lubricants, alkyd resins, acrylates made from trimethylolpropane, plumbing components from polyacetal resins, and controlled-release fertilizers made from urea formaldehyde concentrates (IPCS, 1989), as cited in (ATSDR, 1999). Formaldehyde is used in smaller quantities for the preservation and embalming of biological specimens. It is also used as a germicide, an insecticide, and a fungicide in some products. It is found (as an ingredient or impurity) in some cosmetics and personal hygiene products, such as some soaps, shampoos, hair preparations, deodorants, sunscreens, dry skin lotions, and mouthwashes, mascara and other eye makeup, cuticle softeners, nail creams, vaginal deodorants, and shaving creams (NTP, 2010; IPCS, 2002; ATSDR, 1999).

Formaldehyde is commonly produced as an aqueous solution called formalin, which is used in industrial processes and usually contains about 37–40% formaldehyde and 12–15% methanol. Methanol is added to formalin to slow polymerization that leads eventually to precipitation as paraformaldehyde. Paraformaldehyde has the formula (CH_2_O)_n_, where n is 8 to 100. It is essentially a solid form of formaldehyde and therefore has some of the same uses as formaldehyde (Kiernan, 2000). When heated, paraformaldehyde sublimes as formaldehyde gas. This characteristic makes it useful as a fumigant, disinfectant, and fungicide, such as for the decontamination of laboratories, agricultural premises, and barbering equipment. Long-chain polymers (e.g., Delrin plastic) are less inclined to release formaldehyde, but they have a formaldehyde odor and require additives to prevent decomposition.

The major sources of anthropogenic emissions of formaldehyde are motor vehicles, power plants, manufacturing plants that produce or use formaldehyde or substances that contain formaldehyde (i.e., adhesives), petroleum refineries, coking operations, incineration, wood burning, and tobacco smoke. Among these anthropogenic sources, the greatest volume source of formaldehyde is automotive exhaust from engines not fitted with catalytic converters (NEG, 2003). The Toxic Release Inventory (TRI) data for 2016 show total releases of 19.4 million pounds with about 13 million being stored via underground injection (EPA TRI Explorer, https://enviro.epa.gov/triexplorer/tri_release.chemical).

Formaldehyde is formed in the lower atmosphere by photochemical oxidation of hydrocarbons or other formaldehyde precursors that are released from combustion processes (ATSDR, 1999). Formaldehyde can also be formed by a variety of other natural processes, such as decomposition of plant residues in the soil, by photochemical processes in sea water, and forest fires (NLM, 2019).

The input of formaldehyde into the environment is counterbalanced by its removal by several pathways. Formaldehyde is removed from the air by direct photolysis and oxidation by photochemically produced hydroxyl and nitrate radicals. Measured or estimated half-lives for formaldehyde in the atmosphere range from 1.6 to 19 hours, depending upon estimates of radiant energy, the presence and concentrations of other pollutants, and other factors (ATSDR, 1999). Given the generally short daytime residence times for formaldehyde, there is limited potential for long-range transport (IPCS, 2002). In cases where organic precursors are transported long distances, however, secondary formation of formaldehyde may occur far from the anthropogenic sources of the precursors.

Formaldehyde is released to water from the discharges of both treated and untreated industrial wastewater from its production and from its use in the manufacture of formaldehyde-containing resins (ATSDR, 1999). Formaldehyde is also a possible by-product from using ozone and/or hydrogen peroxide for drinking-water disinfection. In water, formaldehyde is rapidly hydrated to form a glycol, and the equilibrium favors the glycol.

## A.3 HUMAN INHALATION EXPOSURE TO FORMALDEHYDE

Exposure assessments are not conducted or included as part of IRIS toxicological reviews, and authoritative sources on exposure assessment should be consulted. Most recently (as of the time of this assessment), draft formaldehyde exposure assessments are underway in EPA’s TSCA Office (see https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/risk-evaluation-formaldehyde#re-findings). The overview section on human exposure to formaldehyde included in this Appendix is intended to provide context for the analyses of hazard identification and dose-response presented in this assessment. General population exposure to formaldehyde can occur via inhalation, ingestion, and dermal contact, with inhalation exposure representing the primary exposure route. Only inhalation exposure is discussed below. Formaldehyde exposure can occur occupationally via three main scenarios:

- The production of aqueous solutions of formaldehyde (formalin) and their use in the chemical industry (e.g., for the synthesis of various resins), as a preservative in medical laboratories and embalming fluids, and as a disinfectant.
- Release from formaldehyde-based resins in which it is present as a residue and/or through their hydrolysis and decomposition by heat (e.g., during the manufacture of wood products, textiles, synthetic vitreous insulation products, and plastics). In general, the use of phenol-formaldehyde resins results in much lower emissions of formaldehyde than those of urea- and melamine-based resins.
- The pyrolysis or combustion of organic matter (e.g., in engine exhaust gases or during firefighting) (IARC, 2006).

Occupational exposures occur not only during the production of products containing formaldehyde, but also during the use of these products in construction and decoration (Kim et al., 2011). Industries with the greatest potential for exposure include health services, business services, printing and publishing, manufacture of chemicals and allied products, manufacture of apparel and allied products, manufacture of paper and allied products, personal services, machinery (except clerical), transport equipment, and furniture and fixtures (IARC, 1995). Exposure levels for the workers of various professions in a selected number of studies range from 49 to 4,280 μg/m^3^ (40 to 3,480 ppb), with plywood particle board production workers having the highest exposures (Kim et al., 2011).

In recent years, concerns have been raised regarding occupational exposures resulting from the use of semi-permanent professional hair straightening products. In 2010, responding to requests from hair salon employees to the National Institute of Occupational Safety and Health (NIOSH), a study of hair smoothing treatment products marketed as formaldehyde free was conducted. The CDC study (2011) found that the formaldehyde content in a total of 105 samples of these products ranged from 6.8 to 11.8%, with an average of 8.8%. Air samples taken in seven hair salons during smoothing treatments showed 8-hour time-weighted average concentrations of formaldehyde ranging from 7.4 μg/m^3^ (6 ppb) to 407.1 μg/m^3^ (331 ppb) (CDC, 2011). Air concentrations vary depending on factors such as room ventilation, ceiling height, room size, and duration of the treatment (CDC, 2011). Another study by (Pierce et al., 2011) collected air samples during the use of four commercially available hair smoothing products. The hair stylist 8-hour time-weighted average concentrations of formaldehyde ranged from 24.6 μg/m^3^ (20 ppb) to 196.8 μg/m^3^ (160 ppb) for one treatment per day and 61.5 μg/m^3^ (50 ppb) to 922.5 μg/m^3^ (750 ppb) for four consecutive treatments (Pierce et al., 2011). Time weighted average concentrations decreased as the distance from the treatment location increased (Pierce et al., 2011).

EPA’s AirToxScreen (https://www.epa.gov/AirToxScreen; note: a previous version was the National Air Toxics Assessment) provides modeled formaldehyde concentrations based on emissions inventories and meteorological data for areas such as counties, states and the nation and includes the contiguous US, Alaska, Hawaii, Puerto Rico, and Virgin Islands. The range of estimated county mean outdoor air concentrations is 0.1–4.3 μg/m^3^. The breakout by Sector is illustrated in Figure A-2.

Ambient air monitoring data for formaldehyde are available from EPA’s Ambient Monitoring Archive for HAPs which includes data from the Air Quality System database and other data sources (https://www.epa.gov/amtic/amtic-air-toxics-data-ambient-monitoring-archive). Measurement data are collected from National Air Toxic Trends Sites (NATTS) and other sites across the country operated by state, local, and tribal agencies that are not part of the NATTS network. Data for the year 2018 come from 100 monitors located in 27 states and the District of Columbia. The annual means for these monitors range from 0.25–11.06 μg/m^3^ (0.20–9.01 ppb) and have an overall average of 2.97 μg/m^3^ (2.42 ppb). The annual means were derived by EPA through averaging all available daily data from each site that has at least three valid quarters for the year (i.e., a valid quarter is a quarter that contains at least seven daily averages) (https://www.epa.gov/system/files/documents/2021-08/annual-average-statistics-documentation-2018.pdf). Table A-2 presents the data by land use category based on the annual means from each site for 2018. The land use is established in the Air Quality System database from the site description.

Figure A-2 Formaldehyde Ambient Concentrations Contribution by Sector

Source: Based on 2017 AirToxScreen (EPA/OAR).

Table A-2 Ambient air levels by land use category based on 2018 annual site averages

| Annual formaldehyde ambient air concentrations by category (µg/m^3^)
| Agriculture | Commercial | Forest | Industrial | Mobile | Residential
Number of annual averages | 5 | 31 | 4 | 11 | 6 | 43
Mean | 2.02 | 2.88 | 1.98 | 3.42 | 3.80 | 3.00
Minimum | 1.40 | 0.25 | 1.03 | 1.74 | 2.02 | 0.88
Maximum | 2.61 | 4.84 | 3.40 | 8.25 | 5.71 | 11.06

Source: EPA’s Ambient Monitoring Archive for HAPs which includes data from the Air Quality System and other data sources at https://www.epa.gov/amtic/amtic-air-toxics-data-ambient-monitoring-archive.

In general, ambient levels of formaldehyde in outdoor air are significantly lower than those measured in the indoor air of workplaces or residences (IARC, 1995; ATSDR, 1999). Indoor sources of formaldehyde in air include volatilization from pressed wood products, carpets, fabrics, insulation, permanent press clothing, latex paint, and paper bags, along with emissions from gas burners, kerosene heaters, and cigarettes. Kim et al. (2015b) suggested that air fresheners, scented candles, and electric diffusers may also contribute to indoor concentrations of formaldehyde. Indoor air levels are affected by the age of the source materials, temperature, humidity, and ventilation rates (Parthasarathy et al., 2011; (IARC), 2006). Release rates of formaldehyde from consumer products have been published in the literature. Table A-3 presents a selected number of products and their respective emission rates in µg/m^2^-hour.

In general, the major indoor air sources of formaldehyde can be described in two ways: (1) those sources that have the highest emissions when the product is new with decreasing emission over time, as with the first set in the examples above; and (2) those sources that are reoccurring or frequent such as the second set of examples above. Several studies were found in the literature that investigated indoor air concentrations of formaldehyde in various housing types. Median indoor air concentrations in various European countries in both commercial and residential buildings ranged from 10 µg/m^3^ to 50 µg/m^3^ (Sarigiannis et al., 2011). A summary of residential indoor air data in the U.S. and Canada is provided in Table A-4. These are organized by manufactured (i.e., mobile homes/trailers with wheels that are designed to be moved) and conventional housing and in chronological order, beginning with the most recent studies. Results vary depending on housing characteristics and date of study. In general, higher concentrations are found in manufactured houses.

Even though formaldehyde levels in construction materials have declined, indoor inhalation concerns persist. For example, as shown in Table A-4, studies have measured formaldehyde levels in manufactured homes. ATSDR (2007) reported on air sampling in 96 unoccupied trailers provided by the Federal Emergency Management Agency (FEMA) used as temporary housing for people displaced by Hurricane Katrina (see Table A-4). Formaldehyde levels in closed trailers averaged 1,279 ± 849 µg/m^3^ (mean ± standard deviation [SD]) (1.04 ± 0.69 ppm), with a range of 12–4,500 µg/m^3^ (0.01–3.66 ppm). The levels decreased to an average of 480 ± 324 µg/m^3^ (0.39 ± 0.27 ppm), with a range of 0.00–2,005 µg/m^3^ (0.00–1.63 ppm) when the air conditioning was turned on. Levels also decreased to an average of 111 ± 98 µg/m^3^ (0.09 ± 0.08 ppm), with a range of 12–603 µg/m^3^ (0.01–0.49 ppm) when the windows were opened. (ATSDR, 2007) found an association between temperature and formaldehyde levels; higher temperatures were associated with higher formaldehyde levels in trailers with the windows closed. They also noted that different commercial brands of trailers yielded different formaldehyde levels.

In December 2007 and January 2008, the Centers for Disease Control and Prevention (CDC) measured formaldehyde levels in a stratified random sample of 519 FEMA-supplied occupied travel trailers, park models, and mobile homes (“trailers”) (Henry, 2008). At the time of the study, sampled trailers were in use as temporary shelters for Louisiana and Mississippi residents displaced by hurricanes Katrina and Rita. The geometric mean level of formaldehyde in sampled trailers was 95 µg/m^3^ (77 ppb), and the range was 3.7–726 µg/m^3^ (3–590 ppb) (see Table A-4).

Another study by (Maddalena et al., 2008) measured indoor air concentrations for a range of volatile organic compounds (VOCs), including formaldehyde in four unoccupied temporary housing units (i.e., mobile homes) under steady state ventilation conditions. A morning and an afternoon measurement were taken for each unit. The overall average air concentration of formaldehyde for the four mobile homes was 569 µg/m^3^. This is consistent with values measured by (ATSDR, 2007) and CDC (Henry, 2008). Consistently higher air concentrations of formaldehyde were measured in the afternoon samples.

Air concentrations of formaldehyde were lower for conventional housing as shown in Table A-4. Mean values from studies published between 1980 and 2008 ranged from 6.2 to >1,230 µg/m^3^. Although no conclusions could be drawn based on the age of the study alone, some of the studies in Table A-4 suggest that air concentrations are influenced by the age of the house and season of the year. Lower air concentrations were observed as the age of the house increased. Higher concentrations were generally observed during the summer months.

Salthammer et al. (2010) present a thorough review of formaldehyde sources and levels found in the indoor environment. Based on an examination of international studies carried out in 2005 or later they conclude that the average exposure of the population to formaldehyde is 20 to 40 μg/m^3^ under normal living conditions. Figure A-3 summarizes the range of formaldehyde air concentrations in various environments. The dotted line represents the WHO guidelines of 100 μg/m^3^. More recently, (Branco et al., 2015) measured hourly mean formaldehyde concentrations as high as 204 µg/m^3^ in nursery schools in Portugal.

Data on formaldehyde levels in outdoor and indoor air were collected under Canada’s National Air Pollution Surveillance program (IPCS, 2002; Health Canada, 2001). The effort included four suburban and four urban sites sampled in the period 1990–1998. A Monte Carlo analysis applied to the pooled data (n = 151) was used to estimate the distribution of time-weighted 24-hour air exposures. This study suggested that mean levels in outdoor air were 3.3 µg/m^3^ (2.7 ppb) and mean levels in indoor air were 35.9 µg/m^3^ (29.2 ppb) (Health Canada, 2001). The simulation analysis also suggested that general population exposures averaged 33–36 µg/m^3^ (27–30 ppb).

Since the early- to mid-1980s, manufacturing processes and construction practices have been changed to reduce levels of indoor formaldehyde emissions (ATSDR, 1999). A 2008 law enacted by the California Air Resource Board (Final Regulation Order: Airborne Toxic Control Measure to Reduce Formaldehyde Emissions from Composite Wood Products; http://www.arb.ca.gov/regact/2007/compwood07/fro-final.pdf) has limited the amount of formaldehyde that can be released by specific composite wood products (i.e., hardwood plywood, particle board, and medium density fiberboard) sold, supplied, or manufactured for use in California. For this reason, the mean indoor air levels presented by (Health Canada, 2001) (based on samples collected from 1989–1995) may overestimate current levels.

Table A-3 Formaldehyde emission rates from various consumer products

Products | Emission Rate (µg/m^2^-hr) | Reference
Pressed wood products | ND–1,500 | Pickrell et al. (1983)
New clothing | 0.63–31.25 | Pickrell et al. (1983)
Insulation products | 2.17–25.83 | Pickrell et al. (1983)
Paper plates and cups | 3.13–41.67 | Pickrell et al. (1983)
Fabrics | ND–14.58 | Pickrell et al. (1983)
Carpets | ND–2.71 | Pickrell et al. (1983)
Carpets with urethane foam backing | 411–6^a^ | Yu and Crump (1998)
Textile carpet | 83–36^a^ | Yu and Crump (1998)
Carpet with synthetic/PVC fibers | 120–11^a^ | Yu and Crump (1998)
Carpet assembly | 153,000–783^a^ | Yu and Crump (1998)
Carpet underlay | 8,110–12^a^ | Yu and Crump (1998)
Vinyl/PVC flooring | 22,280–91^a^ | Yu and Crump (1998)
Linoleum flooring | 220–22^a^ | Yu and Crump (1998)
Vinyl tiles | 91–45^a^ | Yu and Crump (1998)
Rubber floorings | 1,400^b^ | Yu and Crump (1998)
Soft plastic flooring | 590^b^ | Yu and Crump (1998)
Cork floor tiles | 805–7^a^ | Yu and Crump (1998)
Mineral wool insulation batt | 15–12^b^ | Yu and Crump (1998)
Glass wool fibrous insulation | 4–0.08 | Yu and Crump (1998)
Extruded polystyrene thermal insulants | 1,400–22^a^ | Yu and Crump (1998)
Extruded polyethylene duct and pipe insulants | 0.8–0.28^b^ | Yu and Crump (1998)
Plastic laminated board | 0.4^b^ | Yu and Crump (1998)
Vinyl and fiber glass wallpaper | 300^b^ | Yu and Crump (1998)
PVC foam wallpaper | 230 | Yu and Crump (1998)
PVC wall covering | 100 | Yu and Crump (1998)
Vinyl coated wallpaper | 95–20 | Yu and Crump (1998)
Vinyl wallpaper | 40 | Yu and Crump (1998)
Wallpaper | 100–31 | Yu and Crump (1998)
Vapor barriers (bituminous tar) | 6.3^c^ | Yu and Crump (1998)
Black rubber trim for jointing | 103 | Yu and Crump (1998)
Vinyl covering | 46–30^d^ | Yu and Crump (1998)
Textile wall and floor coverings | 1,600^b^ | Yu and Crump (1998)
Acoustic partitions | 158–6^a^ | Yu and Crump (1998)
Office chair | 1,060–100^a^ | Yu and Crump (1998)
Particle board | 1,500–2,167^e^ 200–28^a^ | Pickrell et al. (1984); Yu (Yu and Crump, 1998)
Plywood | 1,292–1,375^e^; 1,450–44 | Pickrell et al. (1984); Yu and Crump (1998)
Bare urea-formaldehyde wood products (¼– ¾”) | 8.6–1,580^f^ | Kelly et al. (1999)
Coated urea-formaldehyde wood products | <2.7–460^f^ | Kelly et al. (1999)
Permanent press fabric | 42–215^f^ | Kelly et al. (1999)
Decorative laminates | 4.2–51^f^ | Kelly et al. (1999)
Fiberglass products | 16–32^f^ | Kelly et al. (1999)
Bare phenol-formaldehyde wood products | 4.1–9.2^f^ | Kelly et al. (1999)
Paper grocery bags | <0.5^f^ | Kelly et al. (1999)
Paper towels | <0.6^f^ | Kelly et al. (1999)
Latex paint | 326–854^b^ | Kelly et al. (1999)
Fingernail hardener | 178,000–215,500^b^ | Kelly et al. (1999)
Nail polish | 20,700^b^ | Kelly et al. (1999)
Commercially applied urea-formaldehyde floor finish | 421–1,050,000^b^ | Kelly et al. (1999)

a The first number in the range indicates initial emissions; the second number indicates emissions after some time (e.g., hours, days, months).

b Values represent initial emissions.

c 124 days old.

d <98 days old.

e Range indicates different test conditions in temperature and relative humidity.

f Emission rates represent typical conditions, defined as 70 °F, 50% Relative Humidity, and 1 air change per hour.

Table A-4 Studies on residential indoor air levels of formaldehyde

Location (year measured) | Na^a^ | Concentration mean (range); µg/m^3^ | Reference
Manufactured housing
LA & MS, FEMA-supplied temporary housing units (Dec. 2007–Jan. 2008) | 519^b^ | 95 (3.7–726)^c^ | Henry (2008)
FEMA 4 temporary housing units (2007) | 4^b^ | 569 (331–926) | Maddalena et al. (2008)
Baton Rouge, LA, 96 FEMA-supplied temporary housing units (2006); Baseline^d^; Ventilation with air conditioning and bathroom vents only; Ventilation with open windows and vents | 96; 852; 863 | 1,279 (12–4,500); 480 (0–2,005); 111 (12–603) | ATSDR (2007)
Florida, new manufactured house (2000) | NR | 95 (NR) | Hodgson et al. (2002) ^e^
United States, East and Southeast (1997–98) | 4 | 42 (26–58) | Hodgson et al. (2000) ^e^
California, mobile homes (1984–85) | 470 | 86–111(NR) | Sexton et al. (1989) ^f^
United States (NR); Complaint mobile homes Newer mobile homes; Older mobile homes | >500; 260 | 123–1,107 (0–5,166); 1,032; 308 | Gammage and Hawthorne (1985)
Texas, mobile homes whose residents; requested testing (1979–82); Homes < 1 year old; Homes > 1 year old | 443^b^ | NR (ND–9,840); ≥ 2,460 for 27% of homes; ≥ 2,460 for 11.5% of homes | Norsted et al. (1985) ^f^
United States (NR) | 430^b^ | > 1,230 for 4% of samples; 615–1,230 for 18% of samples; 123–615 for 64% of samples; < 123 for 14% of samples | Breysse (1984) ^g^
United States (NR) | 431^b^ | 470 (12–3,599) | Ulsamer et al. (1982) ^g^
United States (NR); Complaint homes, WA, < 2 year old; Complaint homes, WA, 2–10 year old; Complaint homes, MN, < 2 year old; Complaint homes, MN, 2–10 year old; Complaint homes, WI, < 2 year old; Complaint homes, WI, 2–7 year old; Random sample, WI, < 2 year old | 110^b^; 77^b^; 66^b^; 43^b^; 38^b^; 9^b^; NR | 950 (NR); 581 (NR); 1,041 (NR); 339 (NR); 891 (NR); 560 (NR); 661 (NR) | Stone et al., 1981^g^
Wisconsin, complaint homes, 0.2–12 year old (NR) | 65^b^ | 590^h^ (NR) | Dally et al. (1981) ^g^
Conventional housing or unspecified
California (2011-2013) | 352^b^ | 21 (NR) | Vardoulakis et al. (2020)
Cincinnati, Ohio (2011) (median, IQR); Low-income homes, renovated and nonrenovated, all measurements | 96 | 20 (14—33) | Coombs et al. (2016)
Quebec City, Canada (2008–2011) | 83^b^ | 37 (NR) | Vardoulakis et al. (2020)
Summer Field, CA (2006) | 52^b^ | 36 (4.7–143.6) | Offermann et al. (2008)
Québec, Canada (2005) | 96^b^ | 30 (9.6–90) | Gilbert et al. (2006)
Prince Edward Island, Canada (winter 2002) | 59^b^ | 39.0 (5.5–87.5) | Gilbert et al. (2005)
Los Angeles, CA; Houston, TX, and Elizabeth, NJ (summer 1999–spring 2001) | 398 | 22 ± 7.1^i^ | Weisel et al. (2005)
New York City, NY (46 houses) (1999), Los Angeles, CA (41 houses) (2000); NYC (winter); NYC (summer); LA (winter); LA (fall) | 37; 41; 40; 33 | 12 ± 4.7 (5.2–22); 21 ± 11 (5.8–51); 21 ± 11 (7.9–59); 16 ± 6.2 (8.2–32) | Sax et al. (2004)
Canada (1989–1995); Northwest Territories; Windsor, Ontario;; Hamilton, Ontario; Trois-Rivières, Québec; Saskatoon, Saskatchewan | 151 | 36 (12–144) | Environment Canada (2000)
United States, East and Southeast, site-built houses (1997–1998) | 7 | 44^j^ (17–71) | Hodgson et al. (2000) ^e^
Arizona (Jun. 1995–Feb. 1998) | 189 | 21^h^ (max. 408) | Graf et al. (1999)
Louisiana, 53 houses: 75% urban; 25% rural (NR) | 419 | 460 (ND–6,599) | Lemus et al. (1998) ^e^
Boston, MA (1993); winter, 4 residences; summer, 9 residences | 14; 26 | 13.7 (7.4–19.8); 19.8 (7.3–66.2) | Reiss et al. (1995) ^e^
Maryland (1995); Newly built house; 30 days after installation pressed wood | 1^b^ | <94; 55 | Hare et al. (1996)
Colorado (1992–93); Prior to occupancy; After occupancy for 5 months | 9 | 26 (8.0–66); 49 (33.0–81.2) | Lindstrom et al. (1995) ^e^
New Jersey, 6 residential houses (1992) | 36 | 67.1 (33–125) | Zhang et al. (1994)
Arizona, houses (NR) | 202^b^ | 32 (max. 172) | Krzyzanowski et al. (1990) ^d^
United States, residential, various locations (1981–84) | 273 | 44.0^h^ (NR) | Shah and Singh (1988) ^b^
San Francisco, CA, Bay Area (1984); Kitchen; Main bedroom | 48; 45 | 50 (NR); 44 (NR) | Sexton et al. (1986) ^b^
United States (NR); Homes with UFFI; Homes with UFFI | >1,200; 131 | 62–148 (123–4,182); 31–86 (12–209) | Gammage and Hawthorne (1985)
Pullman, WA, houses (NR) | NR | 6.2–89 (NR) | Lamb et al. (1985) ^f^
United States (NR); UFFI houses; Non-UFFI houses and apartments | 244^b^; 59^b^ | > 1,230 for 2.8% of samples; 615–1,230 for 1.9% of samples; 123–615 for 24.1% of samples; < 123 for 71.2% of samples; > 1,230 for 1.8% of samples; 615–1,230 for 1.8% of samples; 123–615 for 36.3% of samples; < 123 for 60.1% of samples | Breysse (1984) ^g^
United States (1982); Houses 0–30 year old; Houses 0–5 year old; Houses 5–15 year old; Houses > 15 year old; Houses 0–5 year old; spring; summer; autumn; Houses 5–15 year old; spring; summer; autumn; Houses > 15 year old; spring; summer; autumn | 40^b^; 18^b^; 11^b^; 11^b^; 18^b^; 11^b^; 11^b^ | 75.9 ± 95.0^i^; 103.0 ± 112.1^i^; 52.0 ± 52.0^i^; 39.0 ± 52.0^i^; 107.0 ± 114.0^i^; 137 ± 125^i^; 58.0 ± 68.0^i^; 53.0 ± 49.0^i^; 60.0 ± 59.0^i^; 41.9 ± 43.1^i^; 44.0 ± 63.0^i^; 36.0 ± 46.0^i^; 32.0 ± 28.0^i^ | Hawthorne et al. (1983) ^g^
United States (1983); Energy-efficient new houses; Low-ventilation modernized houses | 20^b^; 16^b^ | 76 (NR); 37 (NR) | Grimsrud et al. (1983) ^g^
United States (1981); Houses without UFFI; Houses with UFFI | 41^b^; 636^b^ | 40 (12–98); 150 (12–4,200) | Ulsamer et al. (1982) ^g^
United States (1980–81); Houses averaging 2 year old; air-tight construction; mechanical ventilation; Houses averaging 6 year old (loose construction) | 9^b^; 1^b^ | 44 ± 22^i^; 33 ± 20^i^; 17 (NR) | Offerman et al., 1982^g^
United States (1978–79) | 13^b^ | 120^h^ (NR) | Dally et al. (1981) ^g^
United States (1979); Energy-efficient house; Unoccupied house without furniture; Unoccupied house with furniture; Occupied house; day; night | 2^b^ | 98 (40–150); 81 ± 7.0^i^; 225 ± 16.0^i^; 263 ± 26.0^i^; 141 ± 44.0^i^ | Berk et al. (1980) ^g^

Note: Concentrations were converted from ppb to µg/m^3^ for consistency (1 ppb = 1.23 µg/m^3^).

ND = not detected; NR = not reported; UFFI = urea formaldehyde foam insulation; IQR = interquartile range; FEMA = Federal Emergency Management Agency.

a Number of samples unless denoted with footnote (b).

b Number of houses.

c Geometric mean.

d Baseline refers to initial levels measured 4 days prior to intervention phase of the study during which ventilation via air conditioning or open windows was provided.

e Cited in (IARC) (2006).

f Cited in ATSDR (1999).

g Cited in IPCS (1989).

h Median.

i Standard deviation.

Source: Adapted from NTP (2010) and other sources as noted.

Figure A-3 Range of formaldehyde air concentrations (ppb) in different environments

Notes: Graph is in logarithmic scale; “Normal indoor conditions,” “polluted indoor conditions,” and “extreme conditions” were not defined.

Source: Salthammer et al. (2010).

In addition, the Canadian indoor air data may overestimate formaldehyde levels in U.S. homes, because many residential homes in Canada use wood burning stoves more frequently and have tighter construction (due to colder winters), leading to less dilution of indoor emissions. The outdoor air levels, however, appear to have remained fairly constant over recent years, and the median outdoor level from the Canadian study (2.8 µg/m^3^) (2.3 ppb) is very similar to the median of the U.S. monitoring data (2.83 µg/m^3^) (2.3 ppb) in 1999.

Indoor air measurements combined with information about daily activity diaries have been used as surrogate of personal exposures. A recent study conducted with 41 children ages 9–12 years old in Australia concluded that although indoor air measurements from stationary monitors tended to slightly overestimate personal exposures, they were a good surrogate of personal exposures to children (Lazenby et al., 2012). The mean exposure from personal monitors ranged from <5 to 34 µg/m^3^ (<4–26.3 ppb) with a mean of 13.7 µg/m^3^ (11.1 ppb) (Lazenby et al., 2012).