# ABBREVIATIONS

AC50: activity concentration at 50%
ACA: activated aerosol carbon
ADAF: age-dependent adjustment factor
ADH: alcohol dehydrogenase
ADME: absorption, distribution, metabolism, and excretion
AIC: Akaike’s information criterion
ALDH: aldehyde dehydrogenase
ALM: anterior lateral meatus
ALS: amyotrophic lateral sclerosis
ALT: alanine aminotransferase
AML: acute myeloid leukemia
ANCOVA: Analysis of Covariance
ANOVA: Analysis of Variance
AOP: adverse outcome pathway
AST: aspartate aminotransferase
atm: atmosphere
ATS: American Thoracic Society
ATSDR: Agency for Toxic Substances and Disease Registry
AUC: area under the curve
BAL: bronchoalveolar lavage
BBDR: biologically based dose-response
BMC: benchmark concentration
BMCL: benchmark concentration lower confidence limit
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMI: body mass index
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
BW^3/4^: body weight scaling to the 3/4 power
CA: chromosomal aberration
CAA: Clean Air Act
CAS: Chemical Abstracts Service
CASRN: Chemical Abstracts Service registry number
CBMN: cytokinesis-block micronucleus assay
CD: cytokinesis-block micronucleus assay
CE: capillary electrophoresis
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
Cf: confounding
CHO: Chinese hamster ovary (cell line cells)
CI: confidence interval
CL: confidence limit
CML: chronic myeloid leukemia
CNS: central nervous system
COI: conflict of interest
CPAD: Chemical and Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
DMSO: dimethylsulfoxide
DNA: deoxyribonucleic acid
DPX: DNA-protein cross-links
DSB: double-stand breaks
EA: ethyl acetate
ECHRS: European Community Respiratory Health Survey
EPA: Environmental Protection Agency
ER: extra risk
ETS: Environmental tobacco smoke
FA: formaldehyde
FDA: Food and Drug Administration
FEV_1_: forced expiratory volume of 1 second
FSH: follicle stimulating hormone
FVC: forced vital capacity
GD: gestation day
GDH: glutamate dehydrogenase
GGT: γ-glutamyl transferase
GLP: Good Laboratory Practice
GM: granulocyte macrophage
GSD: geometric standard deviation
GSH: glutathione
GST: glutathione-S-transferase
HAP: hazardous air pollutant
HAWC: Health Assessment Workspace Collaborative
Hb/g-A: animal blood:gas partition coefficient
Hb/g-H: human blood:gas partition coefficient
HBCD: hexabromocyclododecane
HEC: human equivalent concentration
HED: human equivalent dose
HERO: Health and Environmental Research Online
HPA: hypothalamus-pituitary-adrenal gland
HPG: hypothalamic-pituitary-gonadal
HSPCs: hematopoietic stem and progenitor cells
IB: information bias
i.p.: intraperitoneal
i.v.: intravenous
IAP: IRIS Assessment Plan
IARC: International Agency for Research on Cancer
ICD: International Classification of Disease
IRIS: Integrated Risk Information System
ISAAC: International Study of Arthritis and Allergies in Children
IUR: inhalation unit risk
JEM: job-exposure matrix
LC_50_: median lethal concentration
LD_50_: median lethal dose
LEC: lowest effective concentration
LHP: lymphohematopoietic
LOAEL: lowest-observed-adverse-effect level
LOEL: lowest-observed-effect level
LRT: lower respiratory tract
MDA: malondialdehyde
MDS: myelodysplastic syndrome
MeSH: Medical Subject Headings
MLE: maximum likehood estimate
MN: micronuclei
MNPCE: micronucleated polychromatic erythrocyte
MOA: mode of action
MOR: mortality odds ratio
MTD: maximum tolerated dose
NA: not available
NALT: nasal-associated lymphoid tissue
NASEM: National Academies of Sciences, Engineering, and Medicine
NATA: National-Scale Air Toxic Assessment
NCI: National Cancer Institute
ND: not detected
NIOSH: National Institute for Occupational Safety and Health
NMD: normalized mean difference
NOAEL: no-observed-adverse-effect level
NOEL: no-observed-effect level
NPC: nasopharyngeal cancer
NR: not reported
NRC: National Research Council
NTP: National Toxicology Program
NZW: New Zealand White (rabbit breed)
OAR: Office of Air and Radiation
OECD: Organisation for Economic Co-operation and Development
OHPC: oro/hypopharyngeal cancer
OLEM: Office of Land and Emergency Management
OR: odds ratio
ORD: Office of Research and Development
OSF: oral slope factor
OVA: ovalbumin
PBPK: physiologically based pharmacokinetic
PECO: populations, exposures, comparators, and outcomes
PEFR: peak expiratory flow rate
PK: pharmacokinetic
PMR: proportionate mortality ratio
PND: postnatal day
POD: point of departure
POD_[ADJ]_: duration-adjusted POD
POE: portal of entry
QSAR: quantitative structure-activity relationship
RBC: red blood cells
RD: relative deviation
RfC: inhalation reference concentration
RfD: oral reference dose
RGDR: regional gas dose ratio
RNA: ribonucleic acid
ROBINS I: Risk of Bias in Nonrandomized Studies of Interventions
RoC: Report on Carcinogens
RR: relative risk
SAR: structure-activity relationship
SB: selection bias
SCC: Squamous cell carcinoma
SCE: sister chromatid exchange
SCF: stem-cell factor
SD: standard deviation
SDH: sorbitol dehydrogenase
SE: standard error
SEM: systematic evidence map
SGOT: serum glutamic oxaloacetic transaminase, also known as AST
SGPT: serum glutamic pyruvic transaminase, also known as ALT
SMR: standardized mortality ratio
SNC: sinonasal cancer
SPIR: standardized proportional incidence ratio
TK: toxicokinetics
TRP: Transient Receptor Potential
TSCATS: Toxic Substances Control Act Test Submissions
TSCE: two-stage clonal expansion
TSFE: time since first exposure
TTP: time-to-pregnancy
TWA: time-weighted average
UCOD: underlying cause of death
UF: uncertainty factor
UF_A_: animal-to-human uncertainty factor
UF_D_: database deficiencies uncertainty factor
UF_H_: human variation uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
URT: upper respiratory tract
WBC: white blood cells
WOS: Web of Science
XRCC: X-ray repair cross-complementing gene