# DERIVATION OF PROVISIONAL VALUES

## DERIVATION OF PROVISIONAL ORAL REFERENCE DOSES

The database of potentially relevant studies for deriving oral reference values for trans-crotonaldehyde includes one subchronic gavage study in rats (Hazleton Laboratories, 1986b), a subchronic gavage study in mice [Hazleton Laboratories (1986a) as cited in NTP-PWG (1987)], a reproductive study in rats (Hazleton Laboratories, 1987), and a chronic drinking water study in rats (Chung et al., 1986). Of the available studies, only Chung et al. (1986) is peer reviewed; however, data reporting for non-neoplastic endpoints in this study is inadequate for evaluation. The two subchronic gavage studies in mice and rats, while not peer reviewed, were performed by a contract research laboratory with extensive documentation of the experimental conditions and methodologies employed. A comprehensive array of endpoints was evaluated in each study, and a review of the pathology results was conducted and confirmed by the NTP-PWG. As part of this review, the NTP-PWG examined the pathology results reported by two independent pathologists, the pathology quality assessment report, and other toxicological data and determined each to be of sufficient scientific quality. Therefore, although there is no explicit indication that these studies were performed under Good Laboratory Practice (GLP) guidelines, review of the study design and data report by the NTP-PWG sufficiently increases confidence in the ability to use these data to derive provisional reference dose (p-RfD) values.

### Derivation of a Subchronic Provisional Reference Dose

Available unpublished repeated-dose subchronic gavage studies in rats and mice identify the forestomach as the most sensitive target of toxicity [Hazelton Laboratories (1986a) as cited in NTP-PWG (1987); Hazleton Laboratories (1986b)]. The lowest identified LOAEL for forestomach lesions is 14 mg/kg-day in female rats. As described above, although not peer reviewed, the Hazleton Laboratories [(1986a) as cited in NTP-PWG (1987); (1986b)] studies were performed by a contract laboratory with extensive documentation of experimental and laboratory conditions. Furthermore, the accompanying data and histological results were evaluated by the NTP-PWG for accuracy. Because forestomach lesions were observed in both sexes of mice and rats and the data were reviewed by an independent party (NTP-PWG), the database supporting the identification of forestomach lesions as a viable critical effect is of sufficient confidence to warrant the development of p-RfDs within the main body of this assessment.

In addition to the significantly elevated rates of forestomach lesions, several other pathologies were observed to be significantly altered relative to control-treated animals. An increased rate of nasal inflammation was reported in male and female rats (Hazleton Laboratories, 1986b). Upon review of the reported data, the NTP-PWG concluded that the observed nasal changes should be considered serous exudation (clear, thin, and watery exudate associated with tissue repair and inflammation), and not acute inflammation as concluded in the laboratory report. The exudates were thought to be reactions to the highly volatile trans-crotonaldehyde. As such, exudates were usually present in the early-death rats, which were also observed to have significant levels of oil droplets within the lungs, indicating that these early deaths were likely the result of gavage errors (accidental administration into the lung). Taken together, these data suggest that early-death animals likely had trans-crotonaldehyde deposited into the lungs, where it could readily volatilize into nasal passages. The NTP-PWG suggested that the apparent serous exudations may have been exacerbated by postmortem change in these animals. Combined, these results suggest that the observed nasal effects may be the result of gavage error and may have increased in severity after death of the rats, precluding the use of nasal lesions/serous nasal exudations as a potential critical effect.

Hazleton Laboratories (1986b) also identified significant absolute and relative thymus weight decreases in female rats at the highest dose examined. This was the only evidence to suggest effects in the thymus. Because these effects were observed only in female rats (and not male rats or male or female mice) and because there was 50% mortality in this dose group (only five rats alive at the end of the study), evidence of effects within the thymus are not sufficiently supported and were, therefore, not considered as a potential POD.

Data for forestomach lesions in male and female F344 rats (see Appendix D) reported by Hazleton Laboratories (1986b) were modeled using all available dichotomous models, as appropriate, in the U.S. EPA’s Benchmark Dose Software (BMDS, Version 2.6) (see Appendix E). Data for forestomach lesions in mice were not modeled because incidence data are not available [Hazelton Laboratories (1986a) as cited in NTP-PWG (1987)]. The modeled data for the F344 rat study are shown in Table D-3. ADDs were used for modeling. In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011b), the Agency endorses body-weight scaling to the 3/4 power (i.e., BW^3/4^) as a default to extrapolate toxicologically equivalent doses of orally administered agents from all laboratory animals to humans (calculation of HED) for the purpose of deriving an RfD from effects that are not portal-of-entry effects or effects resulting from direct exposure of neonatal or juvenile animals. Because forestomach lesions following gavage exposure may be portal-of-entry effects, doses were not converted into HEDs prior to modeling. The standard reporting value benchmark response (BMR) for dichotomous data of 10% extra risk was used.

The benchmark dose lower confidence limit (BMDL) (ADD) of 3 mg/kg-day, based on incidence of forestomach hyperplasia in male rats exposed to crotonaldehyde via gavage 5 days/week for 13 weeks (Hazleton Laboratories, 1986b), provides the lowest candidate point of departure (POD value), and was selected as the POD for deriving the subchronic p-RfD. Forestomach lesions are generally believed to be a manifestation of chronic irritation at the portal of entry associated with oral exposure to corrosive chemicals. The forestomach thickening, nodule formation, and hyperplasia reported in male and female rats [Hazelton Laboratories (1986a) as cited in NTP-PWG (1987); Hazleton Laboratories (1986b)] and forestomach hyperplasia reported in male and female mice [Hazelton Laboratories (1986a) as cited in NTP-PWG (1987)] are consistent with the potential consequence of portal-of-entry exposure to an agent promoting chronic irritation.

The subchronic p-RfD is derived by applying a composite uncertainty factor (UF_C_) of 300 (reflecting an interspecies uncertainty factor [UF_A_] of 10, an intraspecies uncertainty factor [UF_H_] of 10, and a database uncertainty factor [UF_D_] of 3) to the selected POD of 3 mg/kg-day.

Subchronic p-RfD = POD ( ADD ) ÷ UF_C_ = 3 mg / kg-day ÷ 300 = 1 × 10^− 2^ mg / kg-day

Table 5 summarizes the uncertainty factors for the subchronic p-RfD for trans-crotonaldehyde.

Table 5 Uncertainty Factors for the Subchronic p-RfD for trans-Crotonaldehyde (CASRN 123-73-9)

UF | Value | Justification
UF_A_ | 10 | A UF_A_ of 10 is applied to account for uncertainty associated with extrapolating from animals to humans. Cross-species dosimetric adjustment (HED calculation) was not performed because the critical endpoint may be a portal-of-entry effect.
UF_D_ | 3 | A UF_D_ of 3 (10^0.5^) is applied to account for deficiencies and uncertainties in the database. The database for oral exposure to trans-crotonaldehyde consists of subchronic toxicity studies in two species, a single chronic carcinogenicity study in male rats, and a 1-generation reproduction study in rats. There are no developmental toxicity studies available following exposure via any route.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility, in the absence of information to assess toxicokinetic and toxicodynamic variability of trans-crotonaldehyde in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMDL.
UF_S_ | 1 | A UF_S_ of 1 is applied because the subchronic POD was derived from a 13-wk study.
UF_C_ | 300 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMDL = benchmark dose lower confidence limit; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Confidence in the subchronic p-RfD for trans-crotonaldehyde is medium, as described in Table 6.

Table 6 Confidence Descriptors for the Subchronic p-RfD for trans-Crotonaldehyde (CASRN 123-73-9)

Confidence Categories | Designation | Discussion
Confidence in study | M | Confidence in the principal study (Hazleton Laboratories, 1986b) is medium. This study is not peer reviewed; however, it used an adequate number of animals (10 rats/sex) at 6 dose levels (including controls). Furthermore, despite a lack of access to the complete data set, a comprehensive suite of endpoints was examined (clinical symptoms, body and organ weights, hematological and clinical chemistry, and pathology), and the data was subsequently reviewed by the NTP-PWG (NTP-PWG, 1987).
Confidence in database | M | Confidence in the database for trans-crotonaldehyde is medium. The relevant database consists of one short-term dietary study in rats (Borriston, 1980a), as well as subchronic gavage studies in rats (Hazleton Laboratories, 1986b) and mice [Hazelton Laboratories (1986a), as cited in NTP-PWG (1987)], one single-generation reproduction study (Hazleton Laboratories, 1987), and one chronic carcinogenicity study (Chung et al., 1986). None of the subchronic studies are peer reviewed; however, the NTP-PWG reviewed and confirmed the data and pathology in the subchronic gavage studies (NTP-PWG, 1987). Generally, data from the mouse study corroborated the effects observed in the similarly designed rat gavage study identified as the principal study. Neurotoxicity and teratogenicity were not evaluated.
Confidence in subchronic p-RfD^a^ | M | The overall confidence in the subchronic p-RfD is medium.

a The overall confidence cannot be greater than the lowest entry in the table (medium).

M = medium; NTP-PWG = National Toxicology Program’s Pathology Working Group; p-RfD = provisional reference dose.

### Derivation of a Chronic Provisional Reference Dose

No adequate chronic oral non-neoplastic data are available. Data from the Chung et al. (1986) study were not considered as the basis for deriving a chronic p-RfD due to incomplete reporting of relevant data as well as inconsistencies in the dose-response of observed liver tumors and inconsistent reporting of degenerative liver lesions accompanying body-weight changes observed in the high-dose male rats. This lack of reporting precludes an analysis of potential precursor effects at the low dose that could underly the chronic toxicity manifested through reduced body weight at the high dose (Chung et al., 1986). Therefore, the BMDL_10_ (ADD) of 3 mg/kg-day for increased incidence of forestomach hyperplasia in male rats exposed to crotonaldehyde via gavage 5 days/week for 13 weeks (Hazleton Laboratories, 1986b) was also selected as the POD for derivation of the chronic p-RfD.

The chronic p-RfD is derived by applying a UF_C_ of 3,000 (reflecting a UF_A_ of 10, a UF_H_ of 10, a UF_D_ of 3, and a subchronic-to-chronic extrapolation uncertainty factor [UF_S_] of 10) to the selected POD of 3 mg/kg-day.

Chronic p-RfD = POD ( ADD ) ÷ UF_C_ = 3 mg / kg-day ÷ 3,000 = 1 × 10^− 3^ mg / kg-day

Table 7 summarizes the uncertainty factors for the chronic p-RfD for trans-crotonaldehyde.

Table 7 Uncertainty Factors for the Chronic p-RfD for trans-Crotonaldehyde (CASRN 123-73-9)

UF | Value | Justification
UF_A_ | 10 | A UF_A_ of 10 is applied to account for uncertainty associated with extrapolating from animals to humans. Cross-species dosimetric adjustment (HED calculation) was not performed because the critical endpoint may be a portal-of-entry effect.
UF_D_ | 3 | A UF_D_ of 3 (10^0.5^) is applied to account for deficiencies and uncertainties in the database. The database for oral exposure to trans-crotonaldehyde consists of subchronic toxicity studies in two species, one chronic carcinogenicity study in rats, and a one-generation reproduction study in rats. There are no developmental toxicity studies available following exposure via any route.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for human variability in susceptibility, in the absence of information to assess toxicokinetic and toxicodynamic variability of trans-crotonaldehyde in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMDL.
UF_S_ | 10 | A UF_S_ of 10 is applied because the chronic POD was derived from a 13-wk study.
UF_C_ | 3,000 | Composite UF = UF_A_ × UF_D_ × UF_H_ × UF_L_ × UF_S_.

BMDL = benchmark dose lower confidence limit; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; p-RfD = provisional reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Confidence in the chronic p-RfD for trans-crotonaldehyde is low, as described in Table 8.

Table 8 Confidence Descriptors for the Chronic p-RfD for trans-Crotonaldehyde (CASRN 123-73-9)

Confidence Categories | Designation | Discussion
Confidence in study | M | Confidence in the principal study (Hazleton Laboratories, 1986b) is medium. This study is not peer reviewed; however, it used a standard number of animals (10 rats/sex) at 6 dose levels (including controls). Furthermore, despite a lack of access to the complete data set, a comprehensive suite of endpoints was examined (clinical symptoms, body and organ weights, hematological and clinical chemistry, and pathology), and the data was subsequently reviewed by the NTP-PWG (NTP-PWG, 1987).
Confidence in database | L | There were no chronic studies identified that investigated non-neoplastic endpoints, so confidence in the chronic database for trans-crotonaldehyde is low. The relevant database consists of one short-term dietary study in rats (Borriston, 1980a), as well as subchronic gavage studies in rats (Hazleton Laboratories, 1986b) and mice [Hazelton Laboratories (1986a) as cited in NTP-PWG (1987)] and one single-generation reproduction study (Hazleton Laboratories, 1987) which found no effects. None of these studies are peer reviewed; however, the NTP-PWG reviewed and confirmed the data and pathology in the subchronic gavage studies (NTP-PWG, 1987). Generally, data from this mouse study corroborated the effects observed in the similarly designed rat gavage study identified as the principal study. Neurotoxicity and teratogenicity were not evaluated.
Confidence in chronic p-RfD^a^ | L | The overall confidence in the chronic p-RfD is low.

a The overall confidence cannot be greater than the lowest entry in the table (low).

L = low; M = medium; NTP-PWG = National Toxicology Program’s Pathology Working Group; p-RfD = provisional reference dose.

## DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

No studies have been identified that were adequate for deriving inhalation toxicity values.

## SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

A summary of the noncancer provisional reference values is shown in Table 9.

Table 9 Summary of Noncancer Reference Values for trans-Crotonaldehyde (CASRN 123-73-9)

Toxicity Type (units) | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (ADD) | UF_C_ | Principal Study
Subchronic p-RfD (mg/kg-d) | Rat/M | Forestomach hyperplasia | 1 × 10^−2^ | BMDL10 | 3 | 300 | Hazleton Laboratories (1986b)
Chronic p-RfD (mg/kg-d) | Rat/M | Forestomach hyperplasia | 1 × 10^−3^ | BMDL10 | 3 | 3,000 | Hazleton Laboratories (1986b)
Subchronic p-RfC (mg/m^3^) | NDr
Chronic p-RfC (mg/m^3^) | NDr

ADD = adjusted daily dose; BMDL = benchmark dose lower confidence limit (subscripts denote benchmark response: i.e., 10 = dose associated with a 10% extra risk in parameter); M = male(s); NDr = not derived; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UF_C_ = composite uncertainty factor.

## PROVISIONAL CARCINOGENICITY ASSESSMENT

A provisional cancer assessment was not prepared for trans-crotonaldehyde. Although IRIS (U.S. EPA, 2005) conducted a cancer assessment for this compound (weight of evidence [WOE] = “C; possible human carcinogen”), the data were not adequate for deriving quantitative estimates of carcinogenic risk by oral or inhalation exposure. Additionally, liver tumor incidence data reported in Chung et al. (1986) could not be modeled due to a lack of dose-response as indicated by a lack of tumorigenesis in the high-dose group (see Table 10).

Table 10 Summary of Cancer Risk Estimates for trans-Crotonaldehyde (CASRN 123-73-9)

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

NDr = not derived; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.