# REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER AND CANCER)

Tables 3A and 3B provide overviews of the relevant noncancer and cancer evidence bases, respectively, for trans-crotonaldehyde and commercial crotonaldehyde, and include all potentially relevant repeated short-term, subchronic, and chronic studies, as well as reproductive and developmental toxicity studies. Principal studies are identified in bold. The phrase “statistical significance” and the term “significant,” used throughout the document, indicates a p-value of < 0.05 unless otherwise specified.

Table 3A Summary of Potentially Relevant Noncancer Data for trans-Crotonaldehyde (CASRN 123-73-9) and Commercial Crotonaldehyde (>95% trans-; CASRN 4170-30-3)

Category^a^ | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry^b^ | Critical Effects | NOAEL^b^ | LOAEL^b^ | Reference (comments) | Notes^c^
Human
ND
Animal
1. Oral (mg/kg-d)
Short term | 5 M/5 F, S-D albino rat, diet, 14 d; Reported target doses: 0, 22, 44, 88, or 175 mg commercial crotonaldehyde/kg-d | M: 0, 19, 36, 73, 139; F: 0, 17, 36, 68, 136 | No exposure-related changes in clinical signs, body weight, organ weight, or gross necropsy | 139 | NDr | Borriston (1980a) | NPR
Subchronic | 10 M/10 F, F344 rat, gavage in corn oil, 5 d/wk, 13 wk; Reported doses:; 0, 2.5, 5, 10, 20, or 40 mg commercial crotonaldehyde/kg-d | 0, 1.8, 4, 7.1, 14, 29 | Epithelial hyperplasia of the forestomach in male and female rats. Thickened forestomach in female rats. Decreased absolute and relative thymus weight in female rats at 13 wk | 7.1 | 14 | Hazleton Laboratories (1986b); NTP-PWG (1987) | NPR, PS
Subchronic | 10 M/10 F, B6C3F1 mice, gavage in corn oil, 5 d/wk, 13 wk; Reported doses:; 0, 2.5, 5, 10, 20, or 40 mg commercial crotonaldehyde/kg-d | 0, 1.8, 4, 7.1, 14, 29 | Epithelial hyperplasia of the forestomach (forestomach thickening and nodules) in male and female mice | NDr | NDr | Hazelton Laboratories (1986a) as summarized by NTP-PWG (1987) | NPR
Reproductive/Developmental | 20 M/20 F, F344 rat, gavage in corn oil, 9 wk (males exposed 61 d prior to mating and during 7-d mating period; females exposed 30 d prior to mating, through mating and gestation to PND 5); Reported doses:; 0, 2.5, 5, or 10 mg commercial crotonaldehyde/kg-d | 0, 2.5, 5, 10 | No adverse reproductive or developmental effects | 10 | NDr | Hazleton Laboratories (1987) | NPR
2. Inhalation (mg/m^3^)
ND

a Duration categories are defined as follows: acute = exposure for ≤24 hours; short term = repeated exposure for 24 hours to ≤30 days; long term (subchronic) = repeated exposure for >30 days ≤10% lifespan for humans (>30 days up to approximately 90 days in typically used laboratory animal species); and chronic = repeated exposure for >10% lifespan for humans (>~90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002).

b Dosimetry: Doses are presented as ADDs (mg/kg-day) for oral noncancer effects and as HECs (mg/m^3^) for inhalation noncancer effects. ADD (mg/kg-day) = reported dose × (days treated per week/7 days per week).

c Notes: NPR = not peer reviewed; PS = principal study.

ADD = adjusted daily dose; F = female(s); HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = no data; NDr = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day; S-D = Sprague-Dawley.

Table 3B Summary of Potentially Relevant Cancer Data for trans-Crotonaldehyde (CASRN 123-73-9)

Category | Number of Male/Female, Strain, Species, Study Type, Reported Doses, Study Duration | Dosimetry^a^ | Critical Effects | Reference (comments) | Notes^b^
Human
ND
Animal
1. Oral (mg/kg-d)
Carcinogenicity | 23–27 M, F344 rat, drinking water, 113 wk; Reported doses: 0, 0.6, or 6.0 mM trans-crotonaldehyde | 0, 0.6, 4.6 | Elevated incidence of liver neoplastic nodules at low dose, but not high dose | Chung et al. (1986) | PR, IRIS
2. Inhalation (mg/m^3^)
ND

a Dosimetry: Oral exposures are expressed as HEDs (mg/kg-day); HEDs are calculated using DAFs, as recommended by U.S. EPA (2011b): HED = ADD (mg/kg-day) × DAF. The DAF is calculated as follows: DAF = (BW_a_ ÷ BW_h_)^1/4^, where BW_a_ = animal body weight and BW_h_ = human body weight, using study body-weight values for BW_a_ and the reference value of 70 kg for BW_h_.

b Notes: IRIS = used by IRIS (U.S. EPA, 2005); PR = peer reviewed.

ADD = adjusted daily dose; BW = body weight; DAF = dosimetric adjustment factor; HED = human equivalent dose; IRIS = Integrated Risk Information System; M = male(s); ND = no data.

## HUMAN STUDIES

Crotonaldehyde is irritating to the skin, eyes, and mucous membranes (ATSDR, 2014; WHO, 2008; ATSDR, 2002; IARC, 1995). Sensitization reactions have been reported in humans following repeated skin exposure to commercial crotonaldehyde (Mellon Institute of Industrial Research, 1942). Irritation of the eyes, mucous membranes, and respiratory tract were reported in a small number of workers exposed to crotonaldehyde (isomer not specified [NS]), along with several other chemicals, during the incineration of polypropylene syringes (Mehta and Liveright, 1986). Headache and irritation of the eyes, nose, and throat were also reported in the majority of workers exposed to crotonaldehyde (NS) (along with several other chemicals) at a small printing and finishing company; some workers also reported difficulty breathing, wheezing, and nausea (Rosensteel and Tanaka, 1976). The measured levels of unspecified isomers of crotanaldehyde ranged from 0.7 to 2.1 mg/m^3^. However, due to multiple chemical exposures, including other known irritants such as formaldehyde, the potential irritative effects of trans-crotonaldehyde cannot be adequately assessed in either of these health surveys.

Concern for increased cancer incidence in workers from an aldehyde factory was reported in an English-language abstract of a German-language study by Bittersohl (1974). Evaluation of this study by WHO (2008) indicated that no conclusions regarding the carcinogenicity of crotonaldehyde (NS) could be made from this study because all workers were smokers and were exposed to several different aldehydes. IARC (1995) also concluded that the data from this study were too sparse to be conclusive.

In a study examining the role of oxidative stress in the etiology of Alzheimer’s disease, Kawaguchi-Niida et al. (2006) used immunohistochemical analysis to measure levels of protein-bound trans-crotonaldehyde in hippocampi obtained at autopsy of Alzheimer’s disease patients and age-matched controls. Intracellularly, crotonaldehyde (NS) is formed during lipid peroxidation and reacts with proteins to form stable adducts with nucleic acids (WHO, 2008). In Alzheimer’s disease patients, statistically significant (p < 0.01) higher levels of protein-bound trans-crotonaldehyde were observed when compared with age-matched controls. In addition, the protein-bound crotonaldehyde was localized in reactive astrocytes and microglia around senile plaques in Alzheimer’s patients.

## ANIMAL STUDIES

### Oral Exposures

#### Short-Term Studies

##### Borriston (1980a)

In a non-peer-reviewed study, groups of albino Sprague-Dawley (S-D) rats (5/sex/group) were exposed to commercial crotonaldehyde (purity not reported) in the diet at target doses of 0, 22, 44, 88, or 175 mg/kg-day for 14 days (Borriston, 1980a). Daily observations and measurements of food consumption were performed, and body weight was recorded weekly. Based on food consumption and body-weight data, the study authors calculated doses of 19 ± 4, 36 ± 7, 73 ± 14, and 139 ± 21 mg/kg-day in males, and 17 ± 4, 36 ± 7, 68 ± 11, and 136 ± 27 mg/kg-day in females. At sacrifice, all animals were subjected to gross necropsy, and the liver and kidney weights were recorded. No organs were examined microscopically.

As described by the study authors, all animals survived until scheduled sacrifice. No clinical signs of toxicity were observed. Body weights, food consumption, and organ weights were comparable among groups. No exposure-related changes were observed at gross necropsy.

The study authors identified a no-observed-adverse-effect level (NOAEL) of 139 mg/kg-day based on a lack of exposure-related effects. A lowest-observed-adverse-effect level (LOAEL) was not identified.

#### Subchronic Studies

##### Hazleton Laboratories (1986b); NTP-PWG (1987)

In a non-peer-reviewed study, groups of F344 rats (10/sex/group) were administered commercial crotonaldehyde (CASRN 4170-30-3) at doses of 0, 2.5, 5, 10, 20, or 40 mg/kg-day via gavage in corn oil, 5 days/week, for up to 13 weeks (Hazleton Laboratories, 1986b). Adjusted daily doses (ADDs)^5^ calculated for this review were 0, 1.8, 4, 7.1, 14, or 29 mg/kg-day. The animals were subjected to twice daily mortality/morbidity checks; food consumption and body weight were recorded weekly. Blood samples were collected on Days 4, 16, and at the beginning of Week 13 for hematology (hemoglobin [Hb], hematocrit [Hct], red blood cell [RBC] count, mean cell volume [MCV], mean cell hemoglobin [MCH], mean cell hemoglobin concentration [MCHC], total and differential white blood cell [WBC] count, platelet count, and RBC, WBC, and platelet morphology) and serum chemistry (sorbitol dehydrogenase [SDH], gamma glutamyl transferase [GGT], alanine aminotransferase [ALT], alkaline phosphatase [ALP], blood urea nitrogen [BUN], and creatinine) analyses. The report suggested that urine samples were also collected but analysis of the samples was not discussed. An assessment of sperm morphology and vaginal cytology was performed at the end of the study on animals in the three lower dose groups and control animals. At sacrifice, all animals were subjected to gross necropsy, and the brain, heart, liver, right kidney, lung, and thymus were weighed. A complete histopathological examination was performed on all gross lesions and tissue masses, all control rats, all rats in the highest dose group with at least 60% survivors at time of sacrifice, and all rats in the higher dose groups in which death occurred prior to study termination. Target organs (nasal cavities and forestomach) from all rats in all groups were also examined microscopically. The National Toxicology Program (NTP) convened a Pathology Working Group (PWG) (NTP-PWG, 1987) to review selected data and slides from this study.

Early deaths (death prior to cessation of the study) occurred at the following incidences in the control through highest dose groups: 0/10, 0/10, 0/10, 3/10, 3/10, and 5/10 for males, and 1/10, 0/10, 1/10, 1/10, 7/10, and 5/10 for females. The NTP-PWG (1987) concluded that nearly all early deaths were associated with gavage trauma and/or oil in the lungs, and that the early deaths should not be used as criteria for selecting doses for a chronic study. The study authors reported that the highest dose males showed a decrease in body-weight gain from Week 11–13 (data not shown in the original report) and a statistically significant 9% decrease in terminal body weight, compared to control. Terminal body weights were comparable to control in other male groups and in females (see Table D-1 and Table D-2). The study authors indicated that statistically significant changes occasionally occurred in hematological and clinical chemistry measures, but no dose- or time-related trends were observed (quantitative data not available). Therefore, these changes were not considered toxicologically relevant by the study authors or the NTP-PWG (1987). Sporadic (not dose dependent) statistically significant differences were also observed in organ weights in some exposed groups (i.e., relative and absolute thymus weights, relative liver weight, relative brain weight, and relative testicle weight as depicted in Table D-1 and Table D-2). Upon review, organ-weight changes were not considered toxicologically significant by the NTP-PWG (1987), with no further explanation provided. Although the sporadic nature of these changes was apparent for most of the above endpoints, it is unclear why the NTP determined that the decreased absolute and relative thymus-weight changes observed in female rats were not toxicologically relevant. Statistically significant results were seen in these animals only at the highest (29 mg/kg-day) dose. No exposure-related changes were observed in male sperm morphology or female estrous cycle.

At gross necropsy, exposure-related lesions were observed only in the forestomach of rats of both sexes in the two highest dose groups; these lesions included thickened forestomach and/or forestomach hyperplasia (see Table D-3). Microscopic examination showed epithelial hyperplasia in the forestomach at ≥7.1 mg/kg-day (adjusted daily dose [ADD]) in male rats (see Table D-3) although the results were not statistically significant. The NTP-PWG (1987) concluded that no-effect levels for forestomach lesions were 5 and 10 mg/kg-day (ADDs: 4 and 7.1 mg/kg-day) for males and females, respectively, noting that the lesion was equivocal in the single affected female in the 7.1-mg/kg-day group. The study authors reported that statistical significance was only reached at 14 mg/kg-day for females and 29 mg/kg-day for males. Thickened forestomach was observed in male rats at 14 mg/kg-day and 29 mg/kg-day, but only reached statistical significance in female rats at 29 mg/kg-day. The only other exposure-related microscopic change reported was described as nasal inflammation in males at ≥7.1 mg/kg-day and females at ≥14 mg/kg-day, but statistical significance was reached only at 29 mg/kg-day in both sexes (see Table D-3). However, the NTP-PWG (1987) concluded that the nasal lesions were serous exudation and not acute inflammation as reported by Hazleton Laboratories (1986b) and that the effect was likely a localized effect from exhaled crotonaldehyde rather than an effect from blood-circulated crotonaldehyde. Importantly, after histological review of lung tissues in early-death rodents, it was determined that gavage error was the likely cause of early mortality in these animals. NTP-PWG (1987) also observed that the serous exudation was usually present in these early-death rats and may have been exacerbated by postmortem change.

In summary, a NOAEL of 7.1 mg/kg-day and a LOAEL of 14 mg/kg-day were identified by the NTP-PWG based on a statistically significant increase in the incidence of forestomach lesions in female rats.

##### Hazleton Laboratories (1986a) as summarized by NTP-PWG (1987); NTP (2018)

Hazleton Laboratories (1986a) is a companion study to the 13-week study in F344 rats by Hazleton Laboratories (1986b) that is available only as a summary in a report by NTP-PWG (1987). The Hazleton studies are non-peer-reviewed study reports but were reviewed by the NTP-PWG. Selected data tables are also on the NTP Chemical Effects in Biological Systems (CEBS) database (NTP, 2018). In this study, groups of B6C3F1 mice (10/sex/group) were administered commercial crotonaldehyde (CASRN 4170-30-3) at doses of 0, 2.5, 5, 10, 20, or 40 mg/kg-day via gavage in corn oil, 5 days/week for up to 13 weeks. ADDs calculated for this review were 0, 1.8, 4, 7.1, 14, or 29 mg/kg-day. The study followed the same protocol as the companion study in F344 rats (Hazleton Laboratories, 1986b) reported above, but it excluded the hematology and serum chemistry analyses. The forestomach, designated as the target organ based on lesions observed at initial histopathological examination, was examined microscopically in all mice in the control and treated groups. The NTP-PWG (1987) reviewed selected slides from this study.

All mice survived treatment to terminal sacrifice, no clinical signs were observed by the study authors, and they reported no statistically significant differences between treated and control groups for body-weight gain. The study authors reported statistically significant changes in absolute organ weights and organ-/body-weight ratios between the treated and control groups (quantitative data not available), but NTP-PWG (1987) did not consider these differences toxicologically significant because of a lack of consistency or dose-related trend. Treatment-related lesions were not observed at gross necropsy. Microscopic examination showed hyperplasia of the forestomach mucosa in males and females from the highest dose group only. Neither NTP-PWG (1987) nor NTP (2018) reported quantitative data for forestomach lesions. No significant pathological findings were reported for lower dose groups. The NTP-PWG (1987) identified the highest dose as a LOAEL (29 mg/kg-day) for epithelial hyperplasia of the forestomach in both sexes of B6C3F1 mice exposed to commercial crotonaldehyde. Due to the lack of available quantitative data, it is not possible for the purposes of this PPRTV assessment to identify NOAELs and LOAELs for this study.

#### Reproductive/Developmental Studies

##### Hazleton Laboratories (1987)

In a non-peer-reviewed one-generation reproductive study, groups of F344 rats (20/sex/group) were administered commercial crotonaldehyde (CASRN 4170-30-3) via daily gavage in corn oil at doses of 0, 2.5, 5, or 10 mg/kg-day (Hazleton Laboratories, 1987). Males were dosed for 61 days prior to mating and during the 7-day cohabitation period and then sacrificed. Females were dosed for 30 days prior to mating, during mating, and through gestation to Postnatal Day (PND) 5, when they and their surviving pups were sacrificed. Females that did not get pregnant were sacrificed 30 days after the cohabitation period. Mortality checks were performed twice daily. Body weights were recorded weekly, and pregnant females were weighed on Gestation Days (GDs) 0, 7, 14, and 20; at parturition; and again, at sacrifice on PND 5. All females were subjected to a vaginal cytology evaluation prior to mating and again just prior to termination for nonpregnant females. At study termination, all males were subjected to a sperm morphology evaluation, and weights of the right testes and epididymis were recorded. Blood was collected from all animals at termination for possible hormone evaluations. Gross examination was conducted on all animals at necropsy, and histopathology was performed on the reproductive tissues (testes, epididymis, vagina, uterus, cervix, oviducts, and ovaries). Pups were weighed, counted, sexed, and examined at birth and on PND 5.

All animals except for one mid-dose male survived to study termination; the cause of death was reported as not treatment-related. As stated by the study authors, compound-related clinical signs were not evident in any group at any phase of the study. No significant changes in body weights, testis weights, or epididymis weights were observed among any treated male rats compared with control (see Table D-4). In pregnant females, no significant differences from controls in body weights were observed through gestation to PND 5 (see Table D-4). Among female rats that did not get pregnant, there was a significant 20–21% decrease in body-weight gain (and 10–14% decrease in absolute body weight) in the low- and high-dose groups relative to controls during the postmating period (see Table D-4). However, the control group for this analysis included only two animals, and the treated groups also included small numbers (n = 3−5), which limits interpretation of these results and confounds interpretation of the decreased body-weight effect described above. The study authors suggested that this effect was probably not related to treatment due to “the limited number of non-pregnant females and lack of significant findings in the pregnant females.” The data for reproductive and litter parameters showed no effect of treatment. No exposure-related histological lesions in reproductive tissues were observed in males or females. In total, no treatment-related effects were observed for survival or body weight data (parents and pups). Results of the sperm morphology and vaginal cytology studies were not presented.

The high dose of 10 mg/kg-day is identified by the study authors as a NOAEL for parental and reproductive toxicity in this study. No LOAEL is identified.

#### Chronic/Carcinogenicity Studies

##### Chung et al. (1986)

In a peer-reviewed study, groups of male F344 rats (23–27/group) were exposed to trans-crotonaldehyde (>99% purity) in drinking water for 113 weeks at concentrations of 0, 0.6, or 6.0 mM (0, 40, or 420 mg/L, based on molecular weight = 70.09 mg/mmol) beginning at 6 weeks of age (Chung et al., 1986). Average daily doses of 0, 2, and 17 mg/kg-day (HEDs: 0, 0.6, and 4.6 mg/kg-day) were calculated for this review using reported body weights and water consumption. Drinking water consumption was measured twice weekly, and body weight was measured weekly for 40 weeks and then biweekly. Upon sacrifice at the end of exposure, gross necropsy was performed on all animals, and histopathology was assessed on gross lesions and major organs (not specified). Statistics were performed by the study authors for histopathological findings only.

Survival percentages were >95% for the exposed and control groups through 70 weeks of exposure but began to decline thereafter (see Table D-5). At 110 weeks, survival for the control, low-, and high-dose groups was 70% (16/23), 63% (17/27), and 57% (13/23), respectively. These differences in survival rate were not statistically significant. Body weight was decreased in the high-dose group beginning at the 8th week of exposure and continuing throughout the study. Based on estimates derived from graphically presented data, body weights in high-dose animals were more than 10% lower than controls over the latter 6 months of the study, suggesting that the high dose of 4.6 mg/kg-day is at or approaching the maximum tolerated dose (MTD). Body weight in the low-dose group remained similar to controls throughout the study.

Incidence of neoplastic nodules in the liver was significantly elevated at the low dose (9/27), but not the high dose (1/23) compared with controls (0/23) (see Table D-5). Two rats (7% of the 27 animals in the dose group) with neoplastic nodules in the low-dose group also showed hepatocellular carcinomas. This finding was not significant as determined by the study authors. Incidences of altered liver foci, considered to be a preneoplastic lesion by the study authors, were significantly elevated at the low dose (23/27) and the high dose (13/23) compared with controls (1/23) (see Table D-5). The number of altered liver foci per square centimeter was also significantly increased at both doses, with greater increases at the low dose (see Table D-5). Among high-dose rats, the 10/23 individuals that did not have preneoplastic (altered foci) or neoplastic lesions in the liver instead showed moderate to severe degenerative liver damage (fatty metamorphosis, focal liver necrosis, fibrosis, cholestasis, and mononuclear cell infiltration). The report did not discuss whether these 10 rats were the ones that died prior to study termination. The degenerative liver lesions described at the high dose were not reported in the control or low-dose groups. Incidences of neoplastic lesions in tissues other than the liver were not significantly affected by treatment, although it may be noteworthy that bladder tumors were observed in two rats in the low-dose group but not in the control or high-dose rats. There were no reports of non-neoplastic lesions in tissues other than the liver.

A NOAEL and LOAEL cannot be identified from this study due to the limited assessment and reporting of noncancer endpoints and confounding due to the elevated incidence of liver tumors at the low dose, but not at the high dose. Although the reduced body weight in high-dose animals was considered as a potential LOAEL, no mention was made of degenerative liver lesions (a potential precursor effect) in the control and low-dose groups, which were observed to accompany the decreased body weight in the high-dose animals. Due to this lack of reporting on potential precursor effects, it is uncertain that attributing a LOAEL to these non-neoplastic effects would be health protective. Therefore, this study was not included in the “Summary of Potentially Relevant Noncancer Data” table (see Table 3A) above. The study is also of limited value as a quantitative cancer bioassay due to the small group sizes, use of a single sex and species, and the lack of the expected dose-response relationship in the observed tumor data. The latter may reflect that the high dose in this study exceeded the MTD, which is suggested by both the decrease in body weight and the occurrence of degenerative liver lesions in the high-dose group.

### Inhalation Exposures

No adequate inhalation studies have been identified.

## OTHER DATA (SHORT-TERM TESTS, OTHER EXAMINATIONS)

### Genotoxicity Studies

The genotoxicity of trans-crotonaldehyde (CASRN 123-73-9) and commercial crotonaldehyde (CASRN 4170-30-3) has been evaluated primarily in vitro, with a limited number of in vivo studies. Available studies are summarized below (see Table 4A for more details). Based on available data, trans-crotonaldehyde is clastogenic and forms deoxyribonucleic acid (DNA) adducts, both in vitro and in vivo. It is also mutagenic under certain conditions.

Table 4A Summary of trans-Crotonaldehyde (CASRN 123-73-9) and Commercial Crotonaldehyde (>95 trans-; CASRN 4170-30-3) Genotoxicity

Endpoint | Test System | Doses/Concentrations Tested | Results without Activation^a^ | Results with Activation^a^ | Comments | References
Genotoxicity studies—prokaryotic organisms
Reverse mutation | Salmonella typhimurium TA98, TA1537, TA7001, TA7002, TA7003, TA7004, TA7005, TA7006, and a mix of TA7000 series | 50–1,000 µg commercial crotonaldehyde | + (TA98, TA7002, TA7004, TA7005, TA7006, mix); − (TA1537, TA7001, TA7003) | NDr | Liquid preincubation study. The TA7000 series contains base-specific tester strains. Compound tested up to a toxic dose. | Gee et al. (1998)
Reverse mutation | S. typhimurium TA98, TA100, TA1535, TA1537, TA1538 | 0.005–10 µL commercial crotonaldehyde/plate | − | − | Plate incorporation assay. Cytotoxicity observed at ≥1 µL/plate. | Litton Bionetics (1979)
DNA damage | Escherichia coli PQ37 | 100 mM commercial crotonaldehyde | − | − | SOS chromotest. | von der Hude et al. (1988)
Genotoxicity studies—mammalian cells in vitro
Mutation | L5178Y/Tk+/− mouse lymphoma cells | 0, 1, 10, 25, 50 µM commercial crotonaldehyde | + | NDr | Thymidine-kinase mutation assay. | Demir et al. (2011)
CA | Human lymphoblastoid cells (Namalwa cell line) | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | + | NDr | The total number of structural aberrations was increased at ≥100 µM. | Dittberner et al. (1995)
CA | Primary human blood lymphocytes | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | + | NDr | The total number of structural aberrations was increased at ≥10 µM. | Dittberner et al. (1995)
CA | CHO cells | 0.5–16 µg commercial crotonaldehyde/mL | + | + | The total number of structural aberrations was increased at 1.6 µg/mL (−S9) and 16 µg/mL (+S9). | Galloway et al. (1987)
SCE | Human lymphoblastoid cells (Namalwa cell line) | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | + | NDr | SCE induced at ≥20 µM. | Dittberner et al. (1995)
SCE | Primary human blood lymphocytes | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | + | NDr | SCE induced at ≥10 µM. | Dittberner et al. (1995)
SCE | CHO cells | 1.6–160 µg commercial crotonaldehyde/mL | + | + | The total number of SCE was increased at ≥0.5 µg/mL (−S9) and ≥1.6 µg/mL (+S9). | Galloway et al. (1987)
MN | Human lymphoblastoid cells (Namalwa cell line) | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | + | NDr | MN induced at ≥40 µM.; Centromere-positive MN were not significantly increased with exposure. | Dittberner et al. (1995)
MN | Primary human blood lymphocytes | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | + | NDr | MN induced at ≥40 µM.; Centromere-positive MN were not significantly increased with exposure. | Dittberner et al. (1995)
Aneuploidy | Primary human blood lymphocytes | 0, 5, 10, 20, 40, 50, 100, 150, 200, 250 µM trans-crotonaldehyde | − | NDr | The number of aneuploid metaphases was not increased at any concentration. | Dittberner et al. (1995)
Genotoxicity studies—mammalian species in vivo
Dominant lethal mutation | Swiss albino mice (20 M) were exposed via i.p. injection in olive oil for 5 d. After final treatment, males were mated with unexposed females for 5 wk. Dams were sacrificed on GDs 14–16 and examined for live and dead implants. | 0, 8, 16, 32 µL trans-crotonaldehyde/kg; Positive control: 40 mg cyclophosphamide | + | NA | Significant increase in the number of dominant lethal mutations in all treated groups. Maximum lethality was observed in the group exposed to 32 µL/kg and mated 15–21 d post-treatment. | Jha et al. (2007)
CA | Swiss albino mice (3 M, 2 F/group) were exposed once via i.p. injection in olive oil. Mice were sacrificed 6, 13, and 24 hr after treatment. Bone marrow was evaluated for CAs. | 0, 8, 16, 32 µL trans-crotonaldehyde/kg; Positive control: 1.5 mg/kg mitomycin C | + | NA | Significant increase in CAs/cell and percent abnormal cells in all treated groups at all time points. | Jha et al. (2007)
CA | Swiss albino mice (5 M/group) were exposed once via i.p. injection in olive oil. Mice were sacrificed 24 hr after treatment. Spermatocytes were evaluated for CAs. | 0, 8, 16, 32 µL trans-crotonaldehyde/kg; Positive control: 25 mg cyclophosphamide | + | NA | Significant increase in percent abnormal cells at ≥16 µL/kg. | Jha et al. (2007)
MN | B6C3F1 mice (10/sex/group) were exposed via gavage in corn oil for 90 d. Erythrocytes were evaluated for MN. | 0, 2.5, 5, 10, 20, 40 mg commercial crotonaldehyde/kg-d | − | NA | NA | Witt et al. (2000)
DNA adducts | F344 rats (4 F/group) were exposed once via gavage in corn oil. Rats were sacrificed 12 or 20 hr after exposure. Major organs were evaluated for adducts. | 0, 200, 300 mg trans-crotonaldehyde/kg | + | NA | 1,N^2^-Propanodeoxyguanosine adducts were identified in treated animals at both dose levels. The highest levels were detected in liver, followed by lung, kidney, and large intestine. Adduct levels at 200 and 300 mg/kg were 2.9 and 3.4 adducts per 10^8^ nucleotides, respectively. No adducts were detected in controls (detection limit 3 adducts per 10^9^ nucleotides). | Budiawan and Eder (2000); Budiawan et al. (2000)
DNA adducts | F344 rats (4 F/group) were exposed for 6 wk (5 d/wk) via gavage in corn oil. Rats were sacrificed 20 hr after final exposure. | 1, 10 mg trans-crotonaldehyde/kg-d | + | NA | 1,N^2^-Propanodeoxyguanosine adducts were identified in treated animals at both dose levels. Adduct levels at 1 and 10 mg/kg were 2.0 and 6.2 adducts per 10^8^ nucleotides, respectively. No adducts were detected in controls (detection limit 3 adducts per 10^9^ nucleotides). | Eder and Budiawan (2001); Budiawan and Eder (2000)
DNA adducts | F344 rats (F, NS) were exposed for 4 wk (5 d/wk) via gavage in corn oil. Rats were sacrificed 24 hr, 1 wk, or 2 wk after final exposure. | 10 mg trans-crotonaldehyde/kg-d | + | NA | 1,N^2^-Propanodeoxyguanosine adducts were identified in treated animals at all time points. The numbers of adducts at 1 and 2 wk postexposure were 69 and 18%, respectively, of the number of adducts 24 hr after final exposure. No adducts were detected in controls (detection limit 3 adducts per 10^9^ nucleotides). | Eder and Budiawan (2001); Budiawan and Eder (2000)
Genotoxicity studies—invertebrates in vivo
Sex-linked recessive lethal | Drosophila melanogaster; males were exposed for 3 d via feeding prior to mating to unexposed females. | 4,000 ppm commercial crotonaldehyde | − | NA | NA | Woodruff et al. (1985)
Sex-linked recessive lethal | D. melanogaster; males were injected with 0.2–0.3 µL 24–48 hr prior to mating to unexposed females. | 3,500 ppm commercial crotonaldehyde | + | NA | 3,500 ppm dose promoted 15% mortality and 4% increase in male sterility. | Woodruff et al. (1985)
Reciprocal translocation | D. melanogaster; males were injected with 0.2–0.3 µL 24–48 hr prior to mating to unexposed females. | 3,500 ppm commercial crotonaldehyde | + | NA | Increased reciprocal translocations observed in sperm after 3 d of storage. | Woodruff et al. (1985)
Mitotic recombination (white/white^+^ eye mosaic bioassay) | D. melanogaster larvae were exposed via feeding for 48 hr. | 0, 10, 25, 50 mM commercial crotonaldehyde | + | NA | Mitotic recombination observed at ≥25 mM. | Demir et al. (2013)
Genotoxicity studies—subcellular systems
DNA adduct | Calf thymus DNA; 8–48-hr incubation. | 0, 90 µL trans-crotonaldehyde | + | NDr | Formed cyclic 1,N^2^-propanodeoxy-guanosine adducts. More adducts formed with longer incubation. | Budiawan and Eder (2000); Budiawan et al. (2000)

a + = positive; ± = weakly positive; − = negative.

CA = chromosomal aberration; CHO = Chinese hamster ovary; DNA = deoxyribonucleic acid; F = female(s); GD = gestation day; i.p. = intraperitoneal; M = male(s); MN = micronuclei; NA = not applicable; NDr = not determined; SCE = sister chromatid exchange.

#### Mutagenicity

Results of Salmonella typhimurium mutation assays for commercial crotonaldehyde in nonmammalian species are mixed (no study specifically indicated that it was testing trans-crotonaldehyde). A study by Gee et al. (1998) using the liquid suspension method reported that commercial crotonaldehyde was mutagenic without metabolic activation in S. typhimurium, and was not tested under conditions of external metabolic activation. A single study using the plate incorporation method reported that commercial crotonaldehyde was not mutagenic, both with and without metabolic activation (Litton Bionetics, 1979). Research has suggested that contradictory results in bacterial assays may be associated with the high cellular toxicity of crotonaldehyde, particularly in standard plate assays using lower bacterial cell densities (Demir et al., 2011).

In mammals, increased dominant lethal mutations were observed in mice following male exposure to trans-crotonaldehyde via intraperitoneal (i.p.) injection for 5 days prior to mating (Jha et al., 2007). In an in vitro mutation study in mammalian cells, commercial crotonaldehyde induced mutations in mouse lymphoma cells without metabolic activation (Demir et al., 2011). In Drosophila melanogaster, sex-linked recessive mutations were induced following exposure to commercial crotonaldehyde via injection, but not oral exposure (Woodruff et al., 1985).

#### Clastogenicity

Chromosomal aberrations (CAs) were induced in both bone marrow cells and spermatocytes in mice exposed once to trans-crotonaldehyde via i.p. injection (Jha et al., 2007). Micronuclei (MN) were not induced in erythrocytes of mice following exposure to commercial crotonaldehyde via gavage for 90 days (Witt et al., 2000). CAs, sister chromatid exchanges (SCEs), and MN were all induced by trans-crotonaldehyde in primary human blood lymphocytes and cultured human lymphoblastoid cells (Dittberner et al., 1995). However, trans-crotonaldehyde did not induce aneuploidy or centromere-positive MN, indicating that observed effects were clastogenic in nature, rather than aneugenic (Dittberner et al., 1995). CAs and SCEs were also induced in Chinese hamster ovary (CHO) cells following in vitro exposure to commercial crotonaldehyde (Galloway et al., 1987). A significant increase in reciprocal translocations and mitotic recombinations were also observed in D. melanogaster following exposure to commercial crotonaldehyde (Demir et al., 2013; Woodruff et al., 1985).

#### DNA Adducts, Damage, and Repair

Numerous studies report that trans-crotonaldehyde can directly bind to DNA, forming DNA adducts. 1,N^2^-Propanodeoxyguanosine DNA adducts were observed in multiple tissues (the highest levels of adducts were detected in the liver, lung, kidney, and large intestine) of F344 rats exposed to trans-crotonaldehyde via a single gavage exposure to doses ≥200 mg/kg or repeated gavage exposures to doses ≥1 mg/kg-day (Eder and Budiawan, 2001; Budiawan and Eder, 2000; Budiawan et al., 2000). DNA adducts persisted several weeks after exposure. 1,N^2^-Propanodeoxyguanosine DNA adducts were also observed in CHO cells, human fibroblast cells, and isolated calf DNA exposed to trans-crotonaldehyde in vitro (Budiawan and Eder, 2000; Budiawan et al., 2000).

DNA damage was not induced in Escherichia coli exposed to commercial crotonaldehyde (with and without activation) in the SOS chromotest (von der Hude et al., 1988).

### Supporting Animal Toxicity Studies

Numerous acute oral and inhalation studies, studies available only from secondary sources or as abstracts, and studies via other routes (e.g., dermal, injection) were identified. The relevant studies are summarized below (see Table 4B for additional details).

Table 4B Other trans-Crotonaldehyde (CASRN 123-73-9) and Commercial Crotonaldehyde (>95% trans-; CASRN 4170-30-3) Studies

Test^a^ | Materials and Methods | Results | Conclusions | References
Supporting evidence—noncancer effects in animals following oral exposure
Acute (oral) | In a range-finding study, S-D rats (2/sex/group) were exposed to 50, 160, 500, 1,600, or 5,000 mg commercial crotonaldehyde/kg via gavage. Rats were observed for 3 d after dosing. | Convulsions observed in all rats exposed to ≥500 mg/kg immediately after dosing, and all rats in these dose groups died within 0.5 hr of dosing. One female died at 160 mg/kg within 1 hr of dosing. No rats died at 50 mg/kg. | FEL: 160 mg/kg (death) | Borriston (1980b); Borriston (1980c)
Acute (oral) | In an LD_50_ study, S-D rats (5/sex/group) were exposed once to 64.5, 107.5, 180, 300, or 500 mg commercial crotonaldehyde/kg via gavage. At the end of the 14-d observation period, all surviving rats were sacrificed. Endpoints evaluated included mortality, clinical signs, body weight, and gross necropsy. | All rats exposed to ≥300 mg/kg died, and 4/5 males and 3/5 females at 180 mg/kg died. All rats survived at ≤107.5 mg/kg. All observed deaths occurred within 24 hr of dosing. Clinical signs of toxicity (salivation, lacrimation, ataxia, lethargy, and convulsions) and decreased body weight were observed prior to death. Gross lesions were observed in lungs (discoloration, mottling, and congestion) and stomach and intestines (distended with gas or fluid) of dead animals. No exposure-related changes were observed in surviving animals. | Rat LD_50_ (95% CI); Male: 165 (107–254) mg/kg; Female: 175 (105–292) mg/kg; Combined: 174 (131–231) mg/kg; FEL: 180 mg/kg (death) | Borriston (1980b); Borriston (1980c)
Acute (oral) | The LD_50_ for commercial crotonaldehyde was determined in groups of rats. No further details were provided. | The reported LD_50_ (95% CI) was 0.22 (0.20–0.25) g/kg. | Rat LD_50_ (95% CI) = 220 (200–250) mg/kg | Mellon Institute of Industrial Research (1948)
Acute (oral) | Albino rats (6 M/group) were exposed once to 0.1 or 1 g commercial crotonaldehyde/kg via gavage in water plus 1% Tergitol. Animals were observed for mortality and clinical signs. Gross necropsy was conducted. | At 1 g/kg, death occurred within 10 min. Prior to death, animals exposed to 1 g/kg showed clinical signs of toxicity (pain, jumping around). Gross necropsy showed pale kidney, excessive peritoneal fluid, and congestion in the liver, stomach, and intestine. The LD_50_ was reported to be approximately 0.3 g/kg. | Rat LD_50_ = 300 mg/kg | Mellon Institute of Industrial Research (1942)
Acute (oral) | The LD_50_ for commercial crotonaldehyde was determined in groups of rats. No further details were provided. | The study authors classified crotonaldehyde as having moderate toxicity via the oral route. | Rat LD_50_ = 300 mg/kg | Kennedy and Graepel (1991)
Supporting evidence—noncancer effects in animals following inhalation exposure
Acute (inhalation) | The LC_50_ for commercial crotonaldehyde was determined in groups of rats. No further details were provided. | The 4-hr rat LC_50_ was 100 ppm. The study authors classified crotonaldehyde as having moderate toxicity via the inhalation route. | 4-hr rat LC_50_ = 286 mg/m^3b^ | Kennedy and Graepel (1991)
Acute (inhalation) | In an LC_50_ study, rats (3/group; sex and strain not reported) were exposed to 0.099, 0.16–0.28, 0.38, 0.48, 1.03, 2.6, 3.6, 6, 37, or 46.5 mg/L of commercial crotonaldehyde for up to 6 hr. Mortality, clinical signs, and body weight were recorded over 2-wk observation period. | Reported LC_50_ was <0.48 mg/L but >0.16–0.28 mg/L. All rats exposed to ≥1.03 mg/L died. At ≥2.6 mg/L, rats died during the first 43–120 min of exposure; at 1.03 mg/L, death occurred 3.5–24 hr after exposure. At 0.48 mg/L, 2/3 rats died within 1 d; surviving rats lost weight. At 0.38 mg/L, all rats died within 48 hr. No deaths were observed in groups exposed to 0.099 or 0.16–0.28 mg/L. Clinical signs were observed in all exposure groups (gasping, nasal irritation, pink extremities, and labored breathing), with serious signs (tremors, prostration, and convulsions) at lethal doses. | 6-hr rat LC_50_ (range) = 280–480 mg/m^3c^; FEL: 380 mg/m^3^ (death) | Eastman Kodak (1961)
Acute (inhalation) | Rats (4/group; strain and sex not specified) were exposed to air saturated with commercial crotonaldehyde for 1 or 10 min. Rats were held for 7-d observation period. | All rats exposed for 10 min died on the same day of exposure; all rats exposed for 1 min survived. The LT_50_ was determined to be 3 min. | Exposure to air saturated with commercial crotonaldehyde will kill 50% of animals after approximately 3 min. | Mellon Institute of Industrial Research (1942)
Acute (inhalation) | Groups of guinea pigs were exposed to 1,000 or 2,000 ppm commercial crotonaldehyde for up to 30 min. No further details were provided. | Mortality at 1,000 ppm was 0% at 5 min, 20% at 10 min, and 50% at 30 min. Mortality at 2,000 ppm was 50% at 15 min and 100% at 30 min. | FEL: 2,870 mg/m^3^ (death)^b^ | Mellon Institute of Industrial Research (1942)
Supporting evidence—noncancer effects in animals following dermal or ocular exposure
Acute (dermal lethality) | The LD_50_ for commercial crotonaldehyde was determined in groups of rabbits. No further details were provided. | Rabbit LD_50_ (95% CI) = 0.38 (0.27–0.52) mL/kg | Rabbit LD_50_ (95% CI) = 330 (230–450) mg/kg^d^ | Mellon Institute of Industrial Research (1948)
Acute (dermal lethality) | Male and female guinea pigs (6–12/group; strain and sex not specified) were exposed to 0.1 or 1 g/kg commercial crotonaldehyde under occluded conditions for 2 or 24 hr. | Mortality was 6/6 at 1 g/kg and 0/6 at 0.1 g/kg for both durations. The LD_50_ was reported to be approximately 0.3 g/kg. Skin was tanned brown. | Guinea pig LD_50_ values:; 2-hr LD_50_ = 300 mg/kg; 24-hr LD_50_ = 300 mg/kg | Mellon Institute of Industrial Research (1942)
Short term (dermal lethality) | Male and female guinea pigs (6–12/group; strain and sex not specified) were exposed to 0.01, 0.1, or 1 g/kg commercial crotonaldehyde under occluded conditions for 4 d. | Mortality was 1/12 at 0.01 g/kg and 6/6 at ≥0.1 g/kg. The LD_50_ was reported to be approximately 0.03 g/kg. Skin was tanned a dark brown with slight necrosis. | 4-d guinea pig LD_50_ = 30 mg/kg | Mellon Institute of Industrial Research (1942)
Acute (ocular irritation) | An eye irritation study with commercial crotonaldehyde was conducted in rabbits. No further details were provided. | Very severe necrosis was observed at 0.001 mL. | Crotonaldehyde is a severe eye irritant. | Mellon Institute of Industrial Research (1942)
Supporting evidence—noncancer effects in animals following exposure via other routes
Acute (i.p.) | Swiss albino mice (5 M/group) were exposed to trans-crotonaldehyde once via i.p. injections of 0, 8, 16, or 32 µL/kg (0, 7, 14, or 27 mg/kg). The frequency of abnormal sperm heads was determined at 1, 3, or 5 wk in spermatozoa, spermatid, and preleptotene spermatogonia, respectively. | Sperm head abnormalities were observed in spermatozoa and spermatid at ≥14 mg/kg and in preleptotene spermatogonia at 27 mg/kg. Common types observed included short hooked, without hook, giant amorphous, and banana. | NA | Jha and Kumar (2006)
Short term (i.p.) | Swiss albino mice (5 M/group) were exposed to trans-crotonaldehyde via daily i.p. injections of 0, 8, 16, or 32 µL/kg-d (0, 7, 14, or 28 mg/kg-d) for 5 d. Males were then mated with groups of 40 unexposed females for 5 wk. | A significant decrease in fertility index was observed at ≥14 mg/kg-d during the 2nd and 3rd wk of mating and at 28 mg/kg-d during the 4th wk of mating. | NA | Jha et al. (2007)

a Acute = exposure for ≤24 hours; short term = repeated exposure for >24 hours, ≤30 days; subchronic = repeated exposure for >30 days, ≤10% lifespan (>30 days up to approximately 90 days in typically used laboratory animal species); chronic = repeated exposure for >10% lifespan for humans (more than approximately 90 days to 2 years in typically used laboratory animal species) (U.S. EPA, 2002).

b Concentration in mg/m^3^ = concentration in ppm × molecular weight (70.09 g/mol) ÷ 24.45.

c Concentration in mg/m^3^ = concentration in mg/L × 1,000 L/m^3^.

d Dose in mg/kg = dose in mL/kg × density (0.869 g/mL) × 1,000 mg/g.

e Dose in mg = dose in nmol × molecular weight (70.09 ng/nmol) × 1 µg/1,000 ng × 1 mg/1,000 µg.

CI = confidence interval; FEL = frank effect level; i.p. = intraperitoneal; LC_50_ = median lethal concentration; LD_50_ = median lethal dose; LT_50_ = medial lethal time; M = male(s); NDr = not determined; S-D = Sprague-Dawley.

#### Supporting Studies for Noncarcinogenic Effects in Animals

##### Acute Oral Toxicity

Acute oral lethality studies with commercial crotonaldehyde reported median lethal dose (LD_50_) values in rats ranging from 165 to 300 mg/kg (Kennedy and Graepel, 1991; Borriston, 1980b, c; Mellon Institute of Industrial Research, 1948, 1942). Mortality was observed at acute oral doses as low as 160 mg/kg, with no mortality observed at doses ≤107.5 mg/kg (Borriston, 1980b, c). Clinical signs observed at lethal doses included salivation, lacrimation, ataxia, excitability followed by lethargy, and convulsions. In the animals that died, gross lesions were observed in the lungs (discoloration, mottling, congestion), stomachs, and intestines (distended with gas or fluid).

##### Acute Inhalation Toxicity

trans-Crotonaldehyde is a potent respiratory irritant. Acute inhalation lethality studies with commercial crotonaldehyde reported a 6-hour median lethal concentration (LC_50_) in rats of 280–480 mg/m^3^ (Eastman Kodak, 1961) and a 4-hour LC_50_ in rats of 286 mg/m^3^ (Kennedy and Graepel, 1991). Exposure to air saturated with commercial crotonaldehyde resulted in the death of 50% of exposed rats within 3 minutes; all rats died within 10 minutes (Mellon Institute of Industrial Research, 1942). Thirty-minute exposure to 2,870 or 5,740 mg/m^3^ killed 50% and 100% of exposed guinea pigs, respectively (Mellon Institute of Industrial Research, 1942). Clinical signs observed at lethal concentrations in these studies included excitation, tremors, convulsions, marked respiratory distress (labored breathing, gasping), lacrimation, nasal irritation, pink extremities, and weight loss. Mild clinical signs of respiratory distress, nasal irritation, and lacrimation were also observed at nonlethal concentrations as low as 99 mg/m^3^. Hemorrhage and hyperemia were observed in the lungs, heart, liver, and kidneys of some animals that died.

##### Ocular and Dermal Toxicity

Commercial crotonaldehyde is a severe eye irritant in rabbits and is classified as a corrosive substance (Mellon Institute of Industrial Research, 1942). In dermal lethality studies, the LD_50_ values in rabbits or guinea pigs following exposure up to 24 hours were 300–330 mg/kg; the 4-day LD_50_ value in guinea pigs was 30 mg/kg (Mellon Institute of Industrial Research, 1948, 1942).

##### Other Route Toxicity

Available injection studies include acute and short-term studies primarily focused on acute lethality or toxicity to the reproductive, hematological, or immune systems.

Decreased male fertility was observed when male mice were given i.p. injections ≥14 mg/kg-day for 5 days prior to mating with unexposed females; fertility was comparable to control at 7 mg/kg-day (Jha et al., 2007). Damage to male germ cells at all stages of spermatogenesis were also observed in mice following single i.p. injections to trans-crotonaldehyde at a dose of 14 mg/kg, but sperm abnormalities were not observed at 7 mg/kg (Jha and Kumar, 2006).

### Absorption, Distribution, Metabolism, and Excretion Studies

No studies evaluating absorption, distribution, or excretion of trans-crotonaldehyde and commercial crotonaldehyde have been identified.

Available studies indicate that trans-crotonaldehyde can be metabolized via oxidation and conjugation with thiols. Specifically, trans-crotonaldehyde has been shown to conjugate with thiols in vitro, including glutathione (GSH) and N-acetylcysteine, and is a substrate for glutathione S-transferase (GST) (van Iersel et al., 1996; Wang et al., 1992). The reaction rates of thiols with crotonaldehyde were 2-mercaptoethanesulfonate > GSH > N-acetylcysteine (Wang et al., 1992).

### Mode-of-Action/Mechanistic Studies

A target of non-neoplastic toxicity in rodents following gavage exposure is the forestomach [Hazleton Laboratories (1986a) as cited in NTP-PWG (1987); Hazleton Laboratories (1986b)]. Observed lesions at this portal of entry are likely due to the irritative and corrosive nature of crotonaldehyde (TRL, 1986). This mechanism is also relevant to observed nasal lesions in the subchronic rat study by Hazleton Laboratories (1986b) because nasal effects were considered to be a localized effect from exhaled crotonaldehyde rather than an effect from blood-circulated crotonaldehyde (NTP-PWG, 1987).

Several in vitro studies in cells from the human or mammalian respiratory tract report alterations following exposure to trans-crotonaldehyde, including cytotoxicity, apoptosis, alterations in immune parameters (e.g., increased cytokine secretion, decreased phagocytic activity of alveolar macrophages), and induction of genes associated with inflammation and oxidative stress (Yang et al., 2013b; Yang et al., 2013a).

As discussed in the “Genotoxicity Studies” section and Table 4A, trans-crotonaldehyde is mutagenic under certain conditions. It has been proposed that cyclic propano DNA adducts associated with crotonaldehyde exposure are highly stable promutagenic lesions and may underlie mutagenicity and subsequent tumor formation following exposure to trans-crotonaldehyde (Voulgaridou et al., 2011). In support, DNA-containing trans-crotonaldehyde-induced adducts was transfected into mammalian COS-7 cells, and replication in the presence of these adducts resulted in the induction of mutations (Fernandes et al., 2005). Known endogenous production of aldehyde cyclic adducts makes the potential role of trans-crotonaldehyde-mediated adduct formation in carcinogenicity unclear. To this point, the liver, which is the site of tumor formation following trans-crotonaldehyde exposure (Chung et al., 1986), shows the highest number of DNA adducts in rats following oral exposure (Budiawan and Eder, 2000; Budiawan et al., 2000).

5 ADD (mg/kg-day) = reported dose × (5 ÷ 7).