# APPENDIX F REFERENCES

ACGIH (American Conference of Governmental Industrial Hygienists). (2018). Crotonaldehyde. In 2018 TLVs and BEIs Based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH.
ATSDR (Agency for Toxic Substances and Disease Registry). (2002). ToxFAQs for crotonaldehyde. Atlanta, GA. https://www.atsdr.cdc.gov/toxfaqs/tf.asp?id=948&tid=197
ATSDR (Agency for Toxic Substances and Disease Registry). (2014). Medical management guidelines for crotonaldehyde. Atlanta, GA. https://www.atsdr.cdc.gov/mmg/mmg.asp?id=947&tid=197
ATSDR (Agency for Toxic Substances and Disease Registry). (2019). Toxic substances portal: Toxicological profiles. Atlanta, GA. http://www.atsdr.cdc.gov/toxprofiles/index.asp
Bittersohl, G. (1974). [Epidemiologic investigations on cancer incidence in workers contacted by acetaldol and other aliphatic aldehydes]. Arch Geschwulstforsch 43: 172–176.4848653
Borriston (Borriston Laboratories). (1980a). 14-Day subchronic toxicity study in rats with 2-butenal [TSCA Submission]. (Study No. 80-022; EPA/OTS Doc #878221649). Temple Hills, MD: Boriston Research Laboratories, Inc. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0510394.xhtml
Borriston (Borriston Laboratories). (1980b). Acute oral toxicity study in rats (LD50) with 2-butenal. (EPA/OTS; Doc #878221647). US EPA.
Borriston (Borriston Laboratories). (1980c). Acute oral toxicity study in rats (LD50) with 2-butenal (addendum to final report). (878221648).
Budiawan, E; Eder, E. (2000). Detection of 1,N(2)-propanodeoxyguanosine adducts in DNA of Fischer 344 rats by an adapted (32)P-post-labeling technique after per os application of crotonaldehyde. Carcinogenesis 21: 1191–1196.10837009
Budiawan, E; Schuler, D; Eder, E. (2000). Development of a 32p-postlabelling method for the detection of 1,n2-propanodeoxyguanosine adducts of crotonaldehyde in vivo. Arch Toxicol 74: 404–414. 10.1007/s002040000142 11043496
CalEPA (California Environmental Protection Agency). (2019). Consolidated table of OEHHA/ARB approved risk assessment health values (September 19, 2019 ed.). Sacramento, CA: California Air Resources Board. https://www.arb.ca.gov/toxics/healthval/contable.pdf
Chung, FL; Tanaka, T; Hecht, SS. (1986). Induction of liver tumors in F344 rats by crotonaldehyde. Cancer Res 46: 1285–1289.3002613
Demir, E; Kaya, B; Soriano, C; Creus, A; Marcos, R. (2011). Genotoxic analysis of four lipid-peroxidation products in the mouse lymphoma assay. Mutat Res 726: 98–103. 10.1016/j.mrgentox.2011.07.001 21763450
Demir, E; Turna, F; Kaya, B; Creus, A; Marcos, R. (2013). Mutagenic/recombinogenic effects of four lipid peroxidation products in Drosophila. Food Chem Toxicol 53: 221–227. 10.1016/j.fct.2012.11.053 23238235
Dittberner, U; Eisenbrand, G; Zankl, H. (1995). Genotoxic effects of the alpha, beta-unsaturated aldehydes 2-trans-butenal, 2-trans-hexenal and 2-trans, 6-cis-nonadienal. Mutat Res 335: 259–265. 10.1016/0165-1161(95)00029-1 8524341
Eastman Kodak (Eastman Kodak Company). (1961). Initial submission: acute inhalation toxicity study of 2-butenal (crotonaldehyde) in rats with cover letter dated 09/21/92 [TSCA Submission]. (EPA/OTS Doc #88-920010705; Case No. 8EHQ-92-12520).
ECHA (European Chemicals Agency). (2018). Registration dossier: Crotonaldehyde. Available online at https://echa.europa.eu/registration-dossier/-/registered-dossier/2037/ (accessed April 2, 2018).
Eder, E; Budiawan, E. (2001). Cancer risk assessment for the environmental mutagen and carcinogen crotonaldehyde on the basis of TD(50) and comparison with 1,N(2)-propanodeoxyguanosine adduct levels. Cancer Epidemiol Biomarkers Prev 10: 883–888.11489755
Fernandes, PH; Kanuri, M; Nechev, LV; Harris, TM; Lloyd, RS. (2005). Mammalian cell mutagenesis of the DNA adducts of vinyl chloride and crotonaldehyde. Environ Mol Mutagen 45: 455–459. 10.1002/em.20117 15690339
Galloway, SM; Armstrong, MJ; Reuben, C; Colman, S; Brown, B; Cannon, C; Bloom, AD; Nakamura, F; Ahmed, M; Duk, S; Rimpo, J; Margolin, BH; Resnick, MA; Anderson, B; Zeiger, E. (1987). Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells evaluations of 108 chemicals [Review]. Environ Mol Mutagen 10: 1–175. 10.1002/em.2850100502 3319609
Gee, P; Sommers, CH; Melick, AS; Gidrol, XM; Todd, MD; Burris, RB; Nelson, ME; Klemm, RC; Zeiger, E. (1998). Comparison of responses of base-specific Salmonella tester strains with the traditional strains for identifying mutagens: the results of a validation study. Mutat Res 412: 115–130. 10.1016/S1383-5718(97)00172-1 9539966
Hazleton Laboratories. (1986a). Thirteen week subchronic study in B6C3F1 mice. Crotonaldehyde. Final Report. Research Triangle Park, NC: National Toxicology Program.
Hazleton Laboratories. (1986b). Thirteen week subchronic study in F344 rats: crotonaldehyde. Rockville, MD: Hazleton Laboratories America, Inc.
Hazleton Laboratories. (1987). Subcronic reproductive toxicity study in F344 rats crotonaldehyde. Rockville, MD: Hazleton Laboratories America, Inc.
HSDB (Hazardous Substances Data Bank). (2005). HSDB: (E)-Crotonaldehyde CASRN: 123-73-9. Available online at https://toxnet.nlm.nih.gov/cgi-bin/sis/search/a?dbs+hsdb:@term+@DOCNO+2871 (accessed June 20, 2019).
IARC (International Agency for Research on Cancer). (1995). Crotonaldehyde. In Dry cleaning, some chlorinated solvents and other industrial chemicals (pp. 373–391). Lyon, France. https://monographs.iarc.fr/ENG/Monographs/vol63/mono63-15.pdf
IPCS (International Programme on Chemical Safety). (2020). INCHEM: Chemical safety information from intergovernmental organizations [Database]. Geneva, Switzerland: World Health Organization, Canadian Centre for Occupational Health and Safety. Inter-Organization Programme for the Sound Management of Chemicals. Retrieved from http://www.inchem.org/
Jha, AM; Kumar, M. (2006). In vivo evaluation of induction of abnormal sperm morphology in mice by an unsaturated aldehyde crotonaldehyde. Mutat Res Genet Toxicol Environ Mutagen 603: 159–163. 10.1016/j.mrgentox.2005.11.010
Jha, AM; Singh, AC; Sinha, U; Kumar, M. (2007). Genotoxicity of crotonaldehyde in the bone marrow and germ cells of laboratory mice. Mutat Res 632: 69–77. 10.1016/j.mrgentox.2007.04.008 17543575
Kawaguchi-Niida, M; Shibata, N; Morikawa, S; Uchida, K; Yamamoto, T; Sawada, T; Kobayashi, M. (2006). Crotonaldehyde accumulates in glial cells of Alzheimer’s disease brain. Acta Neuropathol 111: 422–429. 10.1007/s00401-006-0044-1 16538519
Kennedy, GL, Jr; Graepel, GJ. (1991). Acute toxicity in the rat following either oral or inhalation exposure. Toxicol Lett 56: 317–326. 10.1016/0378-4274(91)90160-8 2035177
Litton Bionetics. (1979). Mutagenicity evaluation of C-56 (crotonaldehyde) in the Ames Salmonella/microsome plate test (final report) with cover letter dated 03/11/1987. (86870000237). Dallas, TX: Celanese Chemical Company, Inc.
Mehta, M; Liveright, T. (1986). Health hazard evaluation report no. HETA-86-477-1755, Cumberland County Homemaker Home Health Aid Service, Bridgeton, New Jersey. Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/hhe/reports/pdfs/1986-0477-1755.pdf
Mellon Institute of Industrial Research. (1942). Range finding tests on crotonaldehyde with cover letter dated 050286. (878216444). Danbury, CT: Union Carbide Corp.
Mellon Institute of Industrial Research. (1948). Acute oral and dermal toxicity summaries for crotonaldehyde (progress report) with cover letter dated 05/02/86. (EPA Doc #878216448. TSCATS/203896). Submitted under TSCA.
NIOSH (National Institute for Occupational Safety and Health). (1994). Crotonaldehyde: Immediately dangerous to life or health concentrations (IDLH). Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/123739.html
NIOSH (National Institute for Occupational Safety and Health). (2016). NIOSH pocket guide to chemical hazards: Crotonaldehyde. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0157.html
NRC (National Research Council). (2008). Acute exposure guideline levels for selected airborne chemicals: Volume 6. Washington, DC: The National Academies Press. http://www.nap.edu/catalog.php?record_id=12018
NTP-PWG. (1987). 13-week subchronic toxicity test with crotonaldehyde (C56279B) in Fischer 344 rats and B6C3F1 mice. Research Triangle Park: National Toxicology Program.
NTP (National Toxicology Program). (2016). 14th Report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html
NTP (National Toxicology Program). (2018). Crotonaldehyde (4170-30-3). Chemical Effects in Biological Systems (CEBS). Available online at https://manticore.niehs.nih.gov/cebssearch/test_article/4170-30-3 (accessed April 3, 2018).
OSHA (Occupational Safety & Health Administration). (2018a). Air contaminants: Occupational safety and health standards for shipyard employment, subpart Z, toxic and hazardous substances. (OSHA Standard 1915.1000). Washington, DC: U.S. Department of Labor. https://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286
OSHA (Occupational Safety & Health Administration). (2018b). Table Z-1: Limits for air contaminants. Occupational safety and health standards, subpart Z, toxic and hazardous substances. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992 (accessed June 6, 2019).
OSHA (Occupational Safety & Health Administration). (2020). Safety and health regulations for construction: Occupational health and environmental controls: Gases, vapors, fumes, dusts, and mists: Appendix A. Available online at http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629 (accessed June 6, 2019).
Rosensteel, RE; Tanaka, S. (1976). Health hazard evaluation report no. HHE-75-89-344, Rock Hill Printing and Finishing Company, South Carolina. Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/hhe/reports/pdfs/75-89-344.pdf
TRL (Toxicity Research Laboratories). (1986). Rat oral subchronic toxicity study of crotonaldehyde. (TRL Study #032-008). Research Triangle Park, NC: Research Triangle Institute.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes. (EPA/630/P-02/002F). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Integrated Risk Information System (IRIS) chemical assessment summary for crotonaldehyde (CASRN 123-73-9). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0464_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Health effects assessment summary tables for superfund (HEAST): crotonaldehyde (CASRN 123-73-9) [Fact Sheet]. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. https://epa-heast.ornl.gov/heast.php
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose (pp. 1–50). (EPA/100/R-11/0001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance. (EPA/100/R-12/001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance
U.S. EPA (U.S. Environmental Protection Agency). (2016). About acute exposure guideline levels (AEGLs). https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls
U.S. EPA (U.S. Environmental Protection Agency). (2018a). 2018 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/F-18/001). Washington, DC: U.S. Environmental Protection Agency, Office of Water. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2018b). How to access the TSCA inventory. Download the non-confidential TSCA inventory [Database]. Retrieved from http://www2.epa.gov/tsca-inventory/how-access-tsca-inventory
U.S. EPA (U.S. Environmental Protection Agency). (2020). Integrated risk information system. IRIS assessments [Database]. Washington, DC. Retrieved from http://www.epa.gov/iris/
van Iersel, MLP, S; Ploemen, JPH, TM; Struik, I; van Amersfoort, C; Keyzer, AE; Schefferlie, JG; van Bladeren, PJ. (1996). Inhibition of glutathione S-transferase activity in human melanoma cells by alpha,beta-unsaturated carbonyl derivatives. Effects of acrolein, cinnamaldehyde, citral, crotonaldehyde, curcumin, ethacrynic acid, and trans-2-hexenal. Chem Biol Interact 102: 117–132. 10.1016/S0009-2797(96)03739-8
von der Hude, W; Behm, C; Gürtler, R; Basler, A. (1988). Evaluation of the SOS chromotest. Mutat Res 203: 81–94. 10.1016/0165-1161(88)90023-4 3280989
Voulgaridou, GP; Anestopoulos, I; Franco, R; Panayiotidis, MI; Pappa, A. (2011). DNA damage induced by endogenous aldehydes: current state of knowledge [Review]. Mutat Res 711: 13–27. 10.1016/j.mrfmmm.2011.03.006 21419140
Wang, M; Nishikawa, A; Chung, FL. (1992). Differential effects of thiols on DNA modifications via alkylation and Michael addition by alpha-acetoxy-N-nitrosopyrrolidine. Chem Res Toxicol 5: 528–531. 10.1021/tx00028a011 1391618
WHO (World Health Organization). (2008). Concise international chemical assessment document 74: 2-butenal. Geneva, Switzerland. http://www.inchem.org/documents/cicads/cicads/cicad74.pdf
WHO (World Health Organization). (2018). Online catalog for the Environmental Health Criteria (EHC) monographs. Geneva, Switzerland. Retrieved from http://www.who.int/ipcs/publications/ehc/en/
Witt, KL; Knapton, A; Wehr, CM; Hook, GJ; Mirsalis, J; Shelby, MD; Macgregor, JT. (2000). Micronucleated erythrocyte frequency in peripheral blood of B6C3F(1) mice from short-term, prechronic, and chronic studies of the NTP carcinogenesis bioassay program. Environ Mol Mutagen 36: 163–194. 10.1002/1098-2280(2000)36:3<163::AID-EM1>3.0.CO;2-P11044899
Woodruff, RC; Mason, JM; Valencia, R; Zimmering, S. (1985). Chemical mutagenesis testing in Drosophila. V. Results of 53 coded compounds tested for the National Toxicology Program. Environ Mutagen 7: 677–702. 10.1002/em.2860070507 3930237
Yang, BC; Pan, XJ; Yang, ZH; Xiao, FJ; Liu, XY; Zhu, MX; Xie, JP. (2013a). Crotonaldehyde induces apoptosis in alveolar macrophages through intracellular calcium, mitochondria and p53 signaling pathways. J Toxicol Sci 38: 225–235.23535401
Yang, BC; Yang, ZH; Pan, XJ; Xiao, FJ; Liu, XY; Zhu, MX; Xie, JP. (2013b). Crotonaldehyde-exposed macrophages induce IL-8 release from airway epithelial cells through NF-kappa B and AP-1 pathways. Toxicol Lett 219: 26–34. 10.1016/j.toxlet.2013.02.018 23458894