# APPENDIX D DATA TABLES

Table D-1 Terminal Body Weight and Select Organ Weights in Male F344 Rats Exposed to Commercial Crotonaldehyde (CASRN 4170-30-3) via Gavage in Corn Oil for 13 Weeks (5 Days/Week)^a^

Endpoint | Dose Group, mg/kg-d (ADD)
Endpoint | 0 | 2.5 (1.8) | 5 (4) | 10 (7.1) | 20 (14) | 40 (29)
Mortality^b^ | 0/10 (0%) | 0/10 (0%) | 0/10 (0%) | 3/10 (30%) | 3/10 (30%) | 5/10 (50%)
Terminal body weight (g)^c,^ ^d^ | 320.8 ± 18.7 | 323.3 ± 13.6 (+1%) | 336.5 ± 20.9 (+5%) | 333.7 ± 7.2 (+4%) | 318.4 ± 17.8 (−0.7%) | 290.4 ± 15.5^*^ (−9%)
Liver weight^c,^ ^d^; Absolute (g); Relative (%) | 13.35 ± 1.00; 4.163 ± 0.217 | 12.98 ± 0.53 (−3%); 4.023 ± 0.259 (−3%) | 13.03 ± 1.70 (−2%); 3.859 ± 0.284 (−7%) | 14.03 ± 1.03 (+5%); 4.205 ± 0.291 (+1%) | 13.21 ± 1.19 (−1%); 4.147 ± 0.259 (−0.4%) | 12.46 ± 1.01 (−7%); 4.294 ± 0.314 (+3%)
Kidney weight^c,^ ^d^; Absolute (g); Relative (%) | 1.14 ± 0.07; 0.355 ± 0.016 | 1.11 ± 0.09 (−3%); 0.344 ± 0.020 (−3%) | 1.18 ± 0.13 (+4%); 0.349 ± 0.019 (−2%) | 1.13 ± 0.11 (−0.9%); 0.340 ± 0.036 (−4%) | 1.15 ± 0.12 (+0.9%); 0.360 ± 0.027 (+1%) | 1.09 ± 0.11 (−4%); 0.378 ± 0.049 (+6%)
Thymus weight^c,^ ^d^; Absolute (g); Relative (%) | 0.308 ± 0.023; 0.0966 ± 0.0102 | 0.303 ± 0.039 (−2%); 0.0939 ± 0.0118 (−3%) | 0.299 ± 0.046 (−3%); 0.0888 ± 0.0140 (−8%) | 0.314 ± 0.030 (+2%); 0.0941 ± 0.0102 (−3%) | 0.287 ± 0.068 (−7%); 0.0895 ± 0.0168 (−7%) | 0.272 ± 0.049 (−12%); 0.0933 ± 0.0130 (−3%)
Brain weight^c,^ ^d^; Absolute (g); Relative (%) | 2.15 ± 0.09; 0.671 ± 0.033 | 2.10 ± 0.06 (−2%); 0.649 ± 0.015 (−3%) | 2.13 ± 0.09 (−0.9%); 0.633 ± 0.026^*^ (−6%) | 2.15 ± 0.03 (0%); 0.645 ± 0.009 (−4%) | 2.09 ± 0.11 (−3%); 0.658 ± 0.042 (−2%) | 2.08 ± 0.09 (−3%); 0.718 ± 0.045 (+7%)
Testicle weight^c,^ ^d^; Absolute (g); Relative (%) | 1.532 ± 0.095; 0.4784 ± 0.0288 | 1.476 ± 0.114 (−4%); 0.4560 ± 0.0245 (−5%) | 1.509 ± 0.128 (−2%); 0.4490 ± 0.0211 (−6%) | 1.450 ± 0.080 (−5%); 0.4347 ± 0.0257^*^ (−9%) | 1.469 ± 0.131 (−4%); 0.4618 ± 0.0376 (−3%) | 1.452 ± 0.106 (−5%); 0.5001 ± 0.0214 (+5%)

a Hazleton Laboratories (1986b).

b Values denote number of animals showing changes ÷ total number of animals examined (% incidence).

c Data are mean ± SD; n = 5–10/group.

d Value in parentheses is % change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from control (p < 0.05), as reported by the study authors.

ADD = adjusted daily dose; SD = standard deviation.

Table D-2 Terminal Body Weight and Select Organ Weights in Female F344 Rats Exposed to Commercial Crotonaldehyde (CASRN 4170-30-3) via Gavage in Corn Oil for 13 Weeks (5 Days/Week)^a^

Endpoint | Dose Group, mg/kg-d (ADD)
Endpoint | 0 | 2.5 (1.8) | 5 (4) | 10 (7.1) | 20 (14) | 40 (29)
Mortality^b^ | 1/10 (10%) | 0/10 (0%) | 1/10 (10%) | 1/10 (10%) | 7/10 (70%) | 5/10 (50%)
Terminal body weight (g)^c,^ ^d^ | 198.9 ± 7.7 | 200.1 ± 6.6 (+0.6%) | 202.8 ± 3.3 (+2%) | 200.8 ± 13.1 (+1%) | 201.9 ± 4.4 (+2%) | 194.3 ± 8.2 (−2%)
Liver weight^c,^ ^d^; Absolute (g); Relative (%) | 6.80 ± 0.35; 3.419 ± 0.142 | 7.05 ± 0.48 (+4%); 3.525 ± 0.198 (+3%) | 7.20 ± 0.47 (+6%); 3.556 ± 0.264 (+4%) | 6.48 ± 0.63 (−5%); 3.226 ± 0.186 (−6%) | 7.24 ± 0.12 (+6%); 3.587 ± 0.039^*^ (+5%) | 7.13 ± 1.11 (+5%); 3.666 ± 0.542 (+7%)
Kidney weight^c,^ ^d^; Absolute (g); Relative (%) | 0.74 ± 0.06; 0.371 ± 0.029 | 0.73 ± 0.05 (−1%); 0.366 ± 0.024 (−1%) | 0.76 ± 0.05 (+3%); 0.373 ± 0.026 (+0.5%) | 0.75 ± 0.05 (+1%); 0.376 ± 0.018 (+1%) | 0.77 ± 0.03 (+4%); 0.381 ± 0.011 (+3%) | 0.77 ± 0.04 (+4%); 0.396 ± 0.240 (+7%)
Thymus weight^c,^ ^d^; Absolute (g); Relative (%) | 0.261 ± 0.029; 0.1310 ± 0.0131 | 0.259 ± 0.024 (−0.8%); 0.1295 ± 0.0098 (−1%) | 0.251 ± 0.026 (−4%); 0.1239 ± 0.0131 (−5%) | 0.245 ± 0.022 (−6%); 0.1219 ± 0.0087 (−7%) | 0.260 ± 0.062 (−0.4%); 0.1283 ± 0.0293 (−2%) | 0.206 ± 0.023^*^ (−21%); 0.1059 ± 0.0102^*^ (−19%)
Brain weight^c,^ ^d^; Absolute (g); Relative (%) | 2.00 ± 0.10; 1.004 ± 0.055 | 1.98 ± 0.05 (−1%); 0.992 ± 0.035 (−1%) | 2.01 ± 0.06 (+0.2%); 0.990 ± 0.038 (−1%) | 2.01 ± 0.08 (+0.5%); 1.005 ± 0.057 (+0.1%) | 2.04 ± 0.07 (+2%); 1.011 ± 0.046 (+0.7%) | 1.99 ± 0.07 (−0.5%); 1.026 ± 0.054 (+2%)

a Hazleton Laboratories (1986b).

b Values denote number of animals showing changes ÷ total number of animals examined (% incidence).

c Data are mean ± SD; n = 3–10/group.

d Value in parentheses is % change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from control (p < 0.05), as reported by the study authors.

ADD = adjusted daily dose; SD = standard deviation.

Table D-3 Forestomach and Nasal Lesions in F344 Rats Exposed to Commercial Crotonaldehyde (CASRN 4170-30-3) via Gavage in Corn Oil for 13 Weeks (5 Days/Week)^a^

Endpoint^b^ | Dose Group, mg/kg-d (ADD)
Endpoint^b^ | 0 | 2.5 (1.8) | 5 (4) | 10 (7.1) | 20 (14) | 40 (29)
Thickened forestomach; Males; Females | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 2/10 (20%); 0/10 (0%) | 1/10 (10%); 5/10^*^ (50%)
Forestomach nodule; Males; Females | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 3/10 (30%); 2/10 (20%)
Forestomach hyperplasia; Males; Females | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 0/10 (0%) | 3/10 (30%); 1/10^c^ (10%) | 3/10 (30%); 4/10^*^ (40%) | 8/10^*^ (80%); 8/10^*^ (80%)
Nasal inflammation^d^; Males; Females | 0/10 (0%); 1/10 (10%) | 0/10 (0%); 0/10 (0%) | 0/10 (0%); 1/10 (10%) | 3/10 (30%); 1/10 (10%) | 3/10 (30%); 4/10 (40%) | 7/10^*^ (70%); 6/10^*^ (60%)

a Hazleton Laboratories (1986b); NTP-PWG (1987).

b Values denote number of animals showing changes ÷ total number of animals examined (% incidence).

c Lesion reported as “equivocal” by NTP-PWG (1987).

d Reported as nasal inflammation by Hazleton Laboratories (1986b), reclassified as serous exudation by NTP-PWG (1987).

* Significantly different from control by Fisher’s exact probability test (p < 0.05), conducted for this review.

ADD = adjusted daily dose.

Table D-4 Body-Weight Data in F344 Rats Exposed to Commercial Crotonaldehyde (CASRN 4170-30-3) via Gavage in Corn Oil for 9 Weeks (Premating through PND 5)^a^

Endpoint^b,^ ^c^ | Dose Group, mg/kg-d
Endpoint^b,^ ^c^ | 0 | 2.5 | 5 | 10
Males
Body weight (g); Initial; Wk 9 | 115.7 ± 8.17; 305.8 ± 20.24 | 115.8 ± 7.38 (+0.1%); 301.1 ± 18.64 (−2%) | 119.9 ± 6.22 (+4%); 307.3 ± 21.78 (+0.5%) | 115.6 ± 8.99 (−0.1%); 305.6 ± 16.83 (−0.1%)
Body-weight gain (g); Wk 0–9 | 190.1 ± 16.08 | 185.4 ± 16.50 (−2%) | 187.5 ± 17.00 (−1%) | 190.0 ± 14.71 (0%)
Females
Body weight (g); Initial (all); GD 0 (pregnant); GD 20 (pregnant); PND 0 (pregnant); PND 5 (pregnant); GD 9 (nonpregnant) | 106.3 ± 5.74; 158 ± 6.0; 240 ± 16.9; 195.1 ± 9.73; 196.2 ± 11.00; 202.9 ± 0.21 | 108.0 ± 4.69 (+2%); 159 ± 7.9 (+0.6%); 244 ± 14.2 (+2%); 196.9 ± 10.78 (+0.9%); 198.2 ± 9.77 (+1%); 183.6 ± 8.35 (−10%) | 107.8 ± 7.39 (+1%); 161 ± 8.9 (+2%); 250 ± 16.4 (+4%); 197.6 ± 13.57 (+1%); 201.0 ± 12.08 (+2%); 188.9 ± 10.72 (−7%) | 106.6 ± 4.49 (+0.3%); 162 ± 4.4 (+3%); 249 ± 14.0 (+4%); 196.6 ± 9.64 (+0.8%); 199.7 ± 11.06 (+2%); 175.2 ± 7.43 (−14%)
Body-weight gain (g); GDs 0−20 (pregnant); Wk 0−9 (nonpregnant) | 82.0 ± 14.48; 90.6 ± 3.32 | 85.4 ± 9.08 (+4%); 72.6 ± 6.05^*^ (−20%) | 88.6 ± 12.24 (+8%); 82.1 ± 4.46 (−9%) | 87.8 ± 13.58 (+7%); 72.0 ± 2.91^*^ (−21%)

a Hazleton Laboratories (1987).

b Data are mean ± SD; n =19–20 males/group, 20 total females/group (14–16 pregnant females/group, 2–5 nonpregnant females/group).

c Value in parentheses is % change relative to control = [(treatment mean − control mean) ÷ control mean] × 100.

* Significantly different from control (p < 0.05), as reported by the study authors.

GD = gestation day; PND = postnatal day; SD = standard deviation.

Table D-5 Survival and Preneoplastic and Neoplastic Lesions in Male F344 Rats Exposed to trans-Crotonaldehyde (CASRN 123-73-9) in Drinking Water for 113 Weeks^a^

Endpoint | Dose Group, mg/kg-d (HED)
Endpoint | 0 | 2 (0.6) | 17 (4.6)
Survival^b^; 70 wk; 90 wk; 110 wk | 23/23 (100%); 21/23 (91%); 16/23 (70%) | 27/27 (100%); 25/27 (93%); 17/27 (63%) | 22/23 (96%); 18/23 (78%); 13/23 (57%)
Liver tumors^b^; Neoplastic nodule; Hepatocellular carcinoma; Neoplastic nodule or hepatocellular carcinoma | 0/23 (0%); 0/23 (0%); 0/23 (0%) | 9/27^*^ (33%); 2/27 (7%); 9/27^*^ (33%) | 1/23 (4%); 0/23 (0%); 1/23 (4%)
Preneoplastic lesions; Altered liver foci^b^; Number of altered foci/cm^2c^ | 1/23 (4%); 0.1 ± 0.4 | 23/27^*^ (85%); 12.4 ± 7.4^*^ (+124-fold) | 13/23^*^ (57%); 3.5 ± 3.8^*^ (+35-fold)

a Chung et al. (1986).

b Values denote number of animals showing changes ÷ total number of animals examined (% incidence). The differences in terminal survival across groups were not significant based on Fisher’s exact tests conducted for this review.

c Data are mean ± SD for 23–27 rats; value in parentheses is fold-change relative to control = treatment mean ÷ control mean.

* Significantly different from control (p < 0.001), as reported by the study authors.

HED = human equivalent dose; SD = standard deviation.