# APPENDIX C SCREENING PROVISIONAL VALUES

No screening provisional values are derived for trans-crotonaldehyde.