# APPENDIX B DETAILED PECO CRITERIA

Table B-1 Population, Exposure, Comparison, and Outcome (PECO) Criteria

PECO Element | Evidence
Population | Humans, laboratory mammals, and other animal models of established relevance to human health (e.g., Xenopus embryos); mammalian organs, tissues, and cell lines; and bacterial and eukaryote models of genetic toxicity.
Exposure | In vivo (all routes), ex vivo, and in vitro exposure to the chemical of interest, including mixtures to which the chemical of interest may contribute significantly to exposure or observed effects.
Comparison | Any comparison (across dose, duration, or route) or no comparison (e.g., case reports without controls).
Outcome | Any endpoint suggestive of a toxic effect on any bodily system, or mechanistic change associated with such effects. Any endpoint relating to disposition of the chemical within the body.