# APPENDIX A LITERATURE SEARCH STRATEGY

Non-date-limited literature searches were conducted in May 2019 and updated in July 2020 for studies relevant to the derivation of provisional toxicity values for trans-crotonaldehyde (CASRN 123-73-9) and the commercial crotonaldehyde mixture (CASRN 4170-30-3; >95% trans-isomer). Searches were conducted using U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. HERO searches the following databases: PubMed, TOXLINE (including TSCATS1), and Web of Science. The following databases were searched outside of HERO for health-related values: American Conference of Governmental Industrial Hygienists (ACGIH), Agency for Toxic Substances and Disease Registry (ATSDR), California Environmental Protection Agency (CalEPA), Defense Technical Information Center (DTIC), European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), European Chemicals Agency (ECHA), U.S. EPA Chemical Data Access Tool (CDAT), U.S. EPA ChemView, U.S. EPA Integrated Risk Information System (IRIS), U.S. EPA Health Effects Assessment Summary Tables (HEAST), U.S. EPA Office of Water (OW), International Agency for Research on Cancer (IARC), U.S. EPA TSCATS2/TSCATS8e, U.S. EPA High Production Volume (HPV), Chemicals via IPCS INCHEM, European Centre for Ecotoxicology and Toxicology of Chemicals (ECETOC), Japan Existing Chemical Data Base (JECDB), European Chemicals Agency (ECHA), Organisation for Economic Cooperation and Development (OECD) Screening Information Data Sets (SIDS), OECD International Uniform Chemical Information Database (IUCLID), OECD HPV, National Institute for Occupational Safety and Health (NIOSH), National Toxicology Program (NTP), Occupational Safety and Health Administration (OSHA), and World Health Organization (WHO).

## LITERATURE SEARCH STRINGS

### Pubmed

“123-73-9” OR “4170-30-3” OR “2 butenal”[tw] OR “2 E butenal”[tw] OR “2E but 2 enal”[tw] OR “b methylacrolein”[tw] OR “but 2 enal, E”[tw] OR “crotonal”[tw] OR “crotonaldehyde”[tw] OR “crotonaldehydes”[tw] OR “croton aldehyde”[tw] OR “crotonic aldehyde”[tw] OR “crotylaldehyde”[tw] OR “E but 2 en 1 al”[tw] OR “E but 2 enal”[tw] OR “E crotonaldehyd”[tw] OR “trans 2 buten 1 al”[tw] OR “trans but 2 enal”[tw] OR “topanel CA”[tw] OR “UN 1143”[tw]

## WOS

TS=“123 73 9” OR TS=“4170 30 3” OR TS=“2 butenal” OR TS=“2 E butenal” OR TS=“2E but 2 enal” OR TS=“b methylacrolein” OR TS=“but 2 enal E” OR TS=“crotonal” OR TS=“crotonaldehyde” OR TS=“crotonaldehydes” OR TS=“croton aldehyde” OR TS=“crotonic aldehyde” OR TS=“crotylaldehyde” OR TS=“E but 2 en 1 al” OR TS=“E but 2 enal” OR TS=“E crotonaldehyd” OR TS=“trans 2 buten 1 al” OR TS=“trans but 2 enal” OR TS=“topanel CA” OR TS=“UN 1143”) AND ((WC=(“Toxicology” OR “Endocrinology & Metabolism” OR “Gastroenterology & Hepatology” OR “Gastroenterology & Hepatology” OR “Hematology” OR “Neurosciences” OR “Obstetrics & Gynecology” OR “Pharmacology & Pharmacy” OR “Physiology” OR “Respiratory System” OR “Urology & Nephrology” OR “Anatomy & Morphology” OR “Andrology” OR “Pathology” OR “Otorhinolaryngology” OR “Ophthalmology” OR “Pediatrics” OR “Oncology” OR “Reproductive Biology” OR “Developmental Biology” OR “Biology” OR “Dermatology” OR “Allergy” OR “Public, Environmental & Occupational Health”) OR SU=(“Anatomy & Morphology” OR “Cardiovascular System & Cardiology” OR “Developmental Biology” OR “Endocrinology & Metabolism” OR “Gastroenterology & Hepatology” OR “Hematology” OR “Immunology” OR “Neurosciences & Neurology” OR “Obstetrics & Gynecology” OR “Oncology” OR “Ophthalmology” OR “Pathology” OR “Pediatrics” OR “Pharmacology & Pharmacy” OR “Physiology” OR “Public, Environmental & Occupational Health” OR “Respiratory System” OR “Toxicology” OR “Urology & Nephrology” OR “Reproductive Biology” OR “Dermatology” OR “Allergy”)) OR (TS=“rat” OR TS=“rats” OR TS=“mouse” OR TS=“murine” OR TS=“mice” OR TS=“guinea” OR TS=“muridae” OR TS=rabbit* OR TS=lagomorph* OR TS=hamster* OR TS=ferret* OR TS=gerbil* OR TS=rodent* OR TS=“dog” OR TS=“dogs” OR TS=beagle* OR TS=“canine” OR TS=“cats” OR TS=“feline” OR TS=“pig” OR TS=“pigs” OR TS=“swine” OR TS=“porcine” OR TS=monkey* OR TS=macaque* OR TS=baboon* OR TS=marmoset* OR TS=“child” OR TS=“children” OR TS=adolescen* OR TS=infant* OR TS=“worker” OR TS=“workers” OR TS=“human” OR TS=patient* OR TS=“mother” OR TS=“fetal” OR TS=“fetus” OR TS=“citizens” OR TS=“milk” OR TS=“formula” OR TS=epidemio* OR TS=population* OR TS=exposure* OR TS=“questionnaire” OR SO=epidemio*) OR TI=toxic*

## TOXLINE

@SYN0+@OR+(“2+butenal”+”2+E+butenal”+”2E+but+2+enal”+”b+methylacrolein”+” but+2+enal+E”+crotonal+crotonaldehyde+crotonaldehydes+”croton+aldehyde”+”crotonic+alde hyde”+crotylaldehyde+”E+but+2+en+1+al”+”E+but+2+enal”+”E+crotonaldehyd”+”trans+2+bu ten+1+al”+”trans+but+2+enal”+”topanel+CA”+”UN+1143”+@TERM+@rn+123-73-9+@TER M+@rn+4170-30-3)+@NOT+@org+pubmed+pubdart+nih

## TSCATS

@TERM+@rn+”123-73-9”+@org+TSCATS