# 6 DERIVATION OF PROVISIONAL VALUES

## 6.1 DERIVATION OF ORAL REFERENCE DOSES

Subchronic provisional reference doses (p-RfDs) or RfDs are available for eight constituents of the fraction. The critical effects for these subchronic toxicity values are liver and kidney toxicity (n-propylbenzene, based on analogy to ethylbenzene), decreased pain sensitivity (1,3,5-, 1,2,4-, and 1,2,3-TMB), increased kidney weight (tert- and sec-butylbenzene, based on analogy to the chronic RfD for isopropylbenzene), liver histology (n-butylbenzene), and anemia (HFAN). There are nine available chronic RfDs for constituent compounds (isopropylbenzene, in addition to the compounds identified above). The chronic RfDs are based on the same studies and the same points of departure (PODs) as the corresponding subchronic RfDs. The chronic RfD for isopropylbenzene is based on increased kidney weights. Table 6 summarizes the subchronic and chronic RfDs for constituent compounds and mixtures, with PODs, uncertainty factors, critical effects, and confidence descriptors. As shown in Table 6 and discussed in Appendix B, the data available to assess consistency in critical effects across members of the fraction are limited for effects on endpoints other than body weight. The potencies with RfDs being within one order of magnitude of one another are comparable.

Table 6 Available RfD Values for Aromatic Medium Carbon Range Fraction (C9–C10, EC9–EC < 11)^a^

Indicator Chemical or Components | POD (mg/kg-d) | POD Type | UFc | UF Components | p-RfD or RfD (mg/kg-d) | Confidence in p-RfD or RfD^a^ | Critical Effect(s) | Species, Mode, and Duration | Primary Reference (source)
Subchronic
n-Propylbenzene (C9, EC8.94) | 97.1 | NOEL_ADJ_ | 1,000 | UF_A_, UF_H_, UF_S_ | 0.1 ^b^ | Low | Based on ethylbenzene as an analogue; increased liver and kidney weights (hepatic, urinary); histopathologic changes in kidney | Rat, gavage, 5 d/wk for 182 d | Wolf (1956) as cited in U.S. EPA (2009d)
1,3,5-Trimethylbenzene (C9, EC9.15) | 3.5 | BMDL (HED) | 100 | UF_A_, UF_D_, UF_H_ | 0.04 | Low | Decreased pain sensitivity in male Wistar rats^c^ (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
1,2,4-Trimethylbenzene (C9, EC9.36) | 3.5 | BMDL (HED) | 100 | UF_A_, UF_D_, UF_H_ | 0.04 | Low | Decreased pain sensitivity in male Wistar rats^c^ (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
tert-Butylbenzene (C10, EC9.36) | 110 | NOAEL_ADJ_ | 1,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.1 ^b^ | Low | Based on isopropylbenzene as an analogue; increased kidney weight (urinary) | Rat, 5 d/wk for 194 d | Wolf (1956) as cited U.S. EPA (2012b)
sec-Butylbenzene (C10, EC9.57) | 110 | NOAEL_ADJ_ | 1,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.1 ^b^ | Low | Based on isopropylbenzene as an analogue; increased kidney weight (urinary) | Rat, 5 d/wk for 194 d | Wolf (1956) as cited in U.S. EPA (2012a)
1,2,3-Trimethylbenzene (C9, EC9.65) | 3.5 | BMDL (HED) | 100 | UF_A_, UF_D_, UF_H_ | 0.04 | Low | Decreased pain sensitivity in male Wistar rats^c^ (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
n-Butylbenzene (C10, EC9.96) | 137 | BMDL | 1,000 | UF_A_, UF_D_, UF_H_ | 0.1^b^ | Low | Increased incidence of hepatocellular hypertrophy in F_0_ and F_1_ parent male rats (hepatic) | Rat, gavage, two-generation | Izumi et al. (2005) as cited in U.S. EPA (2010)
HFAN (C9–C10) | 85 | BMDL | 300 | UF_A_, UF_D_, UF_H_ | 0.3 ^b^ | Low | Mild anemia, evidenced by a decrease in RBC count (hematological) | Dog, gelatin capsules, 13 wk | Biodynamics (1990b) as cited in U.S. EPA (2009c)
Chronic
Isopropylbenzene (C9, EC8.66) | 110 | NOAEL_ADJ_ | 1,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.1 | Low–medium | Increased average kidney weight in female Wistar rats (urinary) | Rat, 5 d/wk for 194 d | Wolf (1956) as cited in U.S. EPA (1997)
n-Propylbenzene (C9, EC8.94) | 97.1 | NOEL_ADJ_ | 1,000 | UF_A_, UF_H_, UF_S_ | 0.1 ^b^ | Low | Based on ethylbenzene as an analogue; increased liver and kidney weights (hepatic, urinary) | Rat; gavage; 5 d/wk for 182 d | Wolf (1956) as cited in U.S. EPA (2009a)
1,3,5-Trimethylbenzene (C9, EC9.15) | 3.5 | BMDL (HED) | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.01 | Low | Decreased pain sensitivity in male Wistar rats^c^ (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
1,2,4-Trimethylbenzene (C9, EC9.36) | 3.5 | BMDL (HED) | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.01 | Low | Decreased pain sensitivity in male Wistar rats^c^ (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
tert-Butylbenzene (C10, EC9.36) | 110 | NOAEL_ADJ_ | 1,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.1 ^b^ | Low | Based on isopropylbenzene as an analogue; increased kidney weight (urinary) | Rat, 5 d/wk for 194 d | Wolf (1956) as cited U.S. EPA (2012b)
sec-Butylbenzene (C10, EC9.57) | 110 | NOAEL_ADJ_ | 1,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.1 ^b^ | Low | Based on isopropylbenzene as an analogue; increased kidney weight (urinary) | Rat, 5 d/wk for 194 d | Wolf (1956) as cited in U.S. EPA (2012a)
1,2,3-Trimethylbenzene (C9, EC9.65) | 3.5 | BMDL (HED) | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.01 | Low | Decreased pain sensitivity in male Wistar rats^c^ (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
n-Butylbenzene (C10, EC9.96) | 137 | BMDL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.05^b^ | Low | Increased incidence of hepatocellular hypertrophy in F_0_ and F_1_ parent male Crj:CD (SD) IGS rats (hepatic) | Rat, gavage, two-generation | Izumi et al. (2005) as cited in U.S. EPA (2010)
HFAN (C9–C10) | 85 | BMDL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.03 ^b^ | Low | Mild anemia, evidenced by a decrease in RBC count (hematological) | Dog, gelatin capsules, 13 wk | Biodynamics (1990b) as cited in U.S. EPA (2009c)

a Bolded row shows the compound and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening provisional values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

c Toxicity values based on route-to-route extrapolation (inhalation to oral) using a modified PBPK model.

ADJ = adjusted; BMDL = benchmark dose lower confidence limit; C = carbon; EC = equivalent carbon; HED = human equivalent dose; HFAN = high flash aromatic naphtha; NOAEL = no-observed-adverse-effect level; NOEL = no-observed-effect level; PBPK = physiologically based pharmacokinetic; POD = point of departure; PPRTV = provisional peer-reviewed toxicity value; RBC = red blood cell; p-RfD = provisional reference dose; RfD = reference dose; SD = standard deviation; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

### 6.1.1 Oral Noncancer Assessment Using the Indicator Chemical Method for the Aromatic Medium Carbon Range Fraction

If available analytical chemistry data do not identify concentrations of individual chemicals composing this fraction, the subchronic and chronic p-RfDs (0.04 and 0.01 mg/kg-day, respectively) for TMBs are recommended as the indicator chemical for the aromatic medium carbon range fraction U.S. EPA (2016a). Given the limited data, the compounds that resulted in the lowest RfDs for these effects and target tissues were considered as the basis for indicator chemical selection. The RfDs for the TMBs, derived by route-to-route extrapolation (from inhalation to oral) using a modified physiologically based pharmacokinetic (PBPK) model, are based on neurological effects (decreased pain sensitivity; see Section 2.3). Available data generally support the nervous system as a target of the aromatic medium carbon compounds. Evaluation of available data as discussed in Appendix B suggests that use of the TMBs’ RfD values is reasonably anticipated to be protective for effects associated with exposures to other constituents of the fraction. Users of the indicator chemical method should understand that there could be more uncertainty associated with the application of this toxicity value to the aromatic medium carbon range fraction than for its derivation in U.S. EPA (2016b).

The IRIS review of TMBs cited Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b) as the principal study for the subchronic and chronic RfDs. A study summary was not provided in the IRIS assessment; however, the U.S. EPA (2007) PPRTV for 1,2,4-TMB (the compound that served as the driver for the toxicity value) provided the following summary:

In the subchronic experiment, rats were exposed to 1,2,4-trimethylbenzene at concentrations of 0, 25, 100 or 250 ppm (0, 123, 491 or 1,227 mg/m^3^), 6 hours/day, 5 days/week for 3 months and observed for exposure-related clinical signs and body weight effects (Korsak and Rydzyński, 1996). Rotarod performance and hot-plate behavior were measured as indices of the neurotoxicity of trimethylbenzene isomers. Rotarod performance was tested prior to start of the study, weekly during exposure, and 2 weeks after the termination of the exposure. Hot-plate behavior was tested immediately after termination of the exposure. Fisher’s exact test was used for analysis of rotarod performance and the Kruskall-Wallis test used for changes in pain sensitivity (hot plate behavior). Exposures to 1,2,4-trimethylbenzene did not result in any apparent body weight effects or clinical signs of toxicity. However, exposure-related indicators of neurotoxicity were noted. Rotarod performance failure increased in a concentration-related manner in the groups exposed to 1,2,4-trimethylbenzene, but reached the level of statistical significance (40% failure; p < 0.05) only in the highest (1,227 mg/m^3^) exposure group following 8 or 13 weeks of exposure. The incidence of rotarod performance failure in control rats was 0% throughout the study period. Although the mean rotarod performance failure rate in the highest exposure group remained at 30% after a 2-week recovery period, the rate was not significantly different from controls. Pain-sensitivity was also decreased in a concentration dependent manner (evidenced by increased latency of the paw-lick response). As shown in Table 2, the increased latency reached the level of statistical significance in the 491- and 1,227-mg/m^3^ groups. After a 2-week recovery period, the highest (1,227 mg/m^3^) exposure group no longer exhibited a significant difference in pain sensitivity, relative to controls. This study identified a NOAEL of 123 mg/m^3^ and a LOAEL of 491 mg/m^3^ (6 hours/day, 5 days/week) for significantly decreased pain sensitivity.

U.S. EPA (2016a) used PBPK model estimates of internal blood dose metrics for 1,2,4-TMB coupled with benchmark dose (BMD) modeling to generate a POD. First, BMD modeling of the data (for decreased pain sensitivity following 1,2,4-TMB exposure) identified a benchmark concentration lower confidence limit with one standard deviation (BMCL_1SD_) of 140.54 mg/m^3^ (based on external air concentrations and subsequently adjusted for continuous exposure). Using the available PBPK model, the BMCL_1SD_ was converted to a duration-adjusted POD (POD_ADJ_) of 0.099 mg/L. The POD_ADJ_ value represents the internal blood dose metric of average weekly venous blood concentration of 1,2,4-TMB, which is considered by the U.S. EPA to be the most relevant internal dose metric. To derive an oral toxicity value based on these (inhalation) data, an oral exposure component was added to the PBPK model by the U.S. EPA. The model assumed 100% absorption of ingested 1,2,4-TMB. The human PBPK model was run to estimate a human BMDL (HED) that would result from the same weekly average venous blood concentration observed in the POD_ADJ_ in animals (0.099 mg/L). The resultant BMDL (HED) of 3.5 mg/kg-day was used to derive the subchronic and chronic RfDs for 1,2,4-TMB, which was applied to all TMBs (see Table 6).

Confidence in the principal study was low to medium. Although the study was well-conducted, peer-reviewed, and amenable to dose-response analyses (i.e., used an appropriate number of exposure groups), there was uncertainty with respect to the actual concentrations achieved (only target concentrations were reported), and reported measures of variance (type of measures [e.g., standard deviation] not explicitly specified). Confidence in the oral database (for TMBs) was low, because only acute neurotoxicity data and one subchronic toxicity study (for 1,3,5-TMB) were available. Owing to low confidence in the oral database, low to medium confidence in the principal study, and uncertainty associated with the applicability of the PBPK model for route-to-route extrapolation, confidence in the subchronic and chronic RfDs was low. While toxicological data from mixtures such as HFAN might be preferred in some cases, the p-RfD for HFAN is based on a screening value, and the Agency has more confidence in EPA’s IRIS TMB oral assessments as the indicator chemical.

### 6.1.2 Alternative Oral Noncancer Assessment Using the Hazard Index Method for the Aromatic Medium Carbon Range Fraction

If the available analytical chemistry data quantify the concentrations of TMBs, n-propylbenzene, n-butylbenzene, sec-butylbenzene, tert-butylbenzene, or isopropylbenzene separately from the remainder of the aromatic medium carbon range fraction, it is recommended that HQs for the individual chemicals with analytical data be calculated and an HI for the mixture be developed using the calculated HQs.

For subchronic oral exposures, the following subchronic RfDs or p-RfDs can be used as the denominator in the HQ equations: TMBs (0.04 mg/kg-day), n-propylbenzene (0.1 mg/kg-day), n-butylbenzene (0.1 mg/kg-day), sec-butylbenzene (0.1 mg/kg-day), and tert-butylbenzene (0.1 mg/kg-day). In this alternative approach, the subchronic RfD for TMBs (0.04 mg/kg-day) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually (see Table 6).

For chronic oral exposures, the following chronic RfDs or p-RfDs can be used as the denominator in the HQ equations: TMBs (0.01 mg/kg-day), isopropylbenzene (0.1 mg/kg-day), n-propylbenzene (0.1 mg/kg-day), n-butylbenzene (0.05 mg/kg-day), sec-butylbenzene (0.1 mg/kg-day), and tert-butylbenzene (0.1 mg/kg-day). In this alternative approach, the chronic RfD for TMBs (0.01 mg/kg-day) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually (see Table 6).

In some cases, toxicological data from mixtures such as HFAN might be preferred; however, the p-RfD for HFAN is based on a screening value. The Agency has more confidence in an HI approach as an alternative to the indicator chemical approach than for the surrogate mixture approach for this fraction.

## 6.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

The available subchronic and chronic RfC values, with PODs, uncertainty factors, critical effects, and confidence ratings are presented in Table 7. As shown in the table, there are subchronic and chronic RfCs or provisional reference concentrations (p-RfCs) for one mixture (HFAN) and four individual compounds (n-propylbenzene and 1,3,5-, 1,2,4-, and 1,2,3-TMB) relevant to the aromatic medium carbon range fraction. In addition, there is a chronic RfC for isopropylbenzene. Critical effects for the RfCs included maternal toxicity (decreased body weight), developmental toxicity, increased adrenal and kidney weights, and decreased pain sensitivity.

Table 7 Available RfC Values for Aromatic Medium Carbon Range Fraction (C9–C10, EC9–EC < 11)^a^

Indicator Chemical or Components | POD | POD Type (all are HECs) | UFc | UF Components | RfC or p-RfC (mg/m^3^) | Confidence in p-RfC or RfC^a^ | Critical Effect(s) | Species, Mode, and Duration | Primary Reference (source)
Subchronic
n-Propylbenzene (C9, EC8.94) | 434 | NOAEL | 300 | UF_A_, UF_H_, UF_D_ | 1 ^b^ | Low | Based on ethylbenzene as an analogue; developmental toxicity (developmental) | Rat, 6–7 h/d, 7 d/wk for 3 wk prior to mating and GDs 1–19; rabbits, 6–7 h/d, 7 d/wk on GDs 1–24 | Andrews (1981) and Hardin (1981) as cited in U.S. EPA (2009a)
1,3,5-Trimethylbenzene (C9, EC9.15) | 18.15 | BMCL | 100 | UF_A_, UF_H_, UF_D_ | 0.2 | Low–medium | Decreased pain sensitivity in male Wistar rats (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
1,2,4-Trimethylbenzene (C9, EC9.36) | 18.15 | BMCL | 100 | UF_A_, UF_H_, UF_D_ | 0.2 | Low–medium | Decreased pain sensitivity in male Wistar rats (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
1,2,3-Trimethylbenzene (C9, EC9.65) | 18.15 | BMCL | 100 | UF_A_, UF_H_, UF_D_ | 0.2 | Low–medium | Decreased pain sensitivity in male Wistar rats (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
HFAN (C9–C10) | 125 | LOAEL | 100 | UF_A_, UF_H_, UF_L_ | 1^b^ | Moderate | Decreased maternal body weight vs. controls (reproductive) in CD-1 mice | Mouse, 6 h/d, 7 d/wk on GDs 6–15 | McKee et al. (1990) as cited in U.S. EPA (2009c)
Chronic
Isopropylbenzene (C9, EC8.66) | 435 | NOAEL | 1,000 | UF_A_, UF_d_, UF_H_, UF_S_ | 0.4 | Medium | Increased kidney weights in female rats and adrenal weights in male and female F344 rats (endocrine, urinary) | Rat, 6 h/d, 5 d/wk for 13 wk | Cushman (1995) as cited in U.S. EPA (1997)
n-Propylbenzene (C9, EC8.94) | 434 | NOAEL | 300 | UF_A_, UF_D_, UF_H_ | 1 ^b^ | Low | Based on ethylbenzene as an analogue; developmental toxicity (developmental) | Rat, 6–7 h/d, 7 d/wk for 3 wk prior to mating and GDs 1–19; rabbit, 6–7 h/d, 7 d/wk on GDs 1–24 | Andrews (1981) and Hardin (1981) as cited in U.S. EPA (2009a)
1,3,5-Trimethylbenzene (C9, EC9.15) | 18.15 | BMCL | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.06 | Low–medium | Decreased pain sensitivity in male Wistar rats (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
1,2,4-Trimethylbenzene (C9, EC9.36) | 18.15 | BMCL | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.06 | Low–medium | Decreased pain sensitivity in male Wistar rats (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
1,2,3-Trimethylbenzene (C9, EC9.65) | 18.15 | BMCL | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.06 | Low–medium | Decreased pain sensitivity in male Wistar rats (nervous) | Rat, 6 h/d, 5 d/wk for 13 wk | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
HFAN (C9–C10) | 125 | LOAEL | 1,000 | UF_A_, UF_H_, UF_L_, UF_S_ | 0.1^b^ | Moderate | Decreased maternal body weight vs. controls (reproductive) on GD 15 in CD-1 mice | Mouse, 6 h/d, 7 d/wk on GDs 6–15 | McKee et al. (1990) as cited in U.S. EPA (2009c)

a Bolded row shows the compounds and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening provisional values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

BMCL = benchmark concentration lower confidence limit; C = carbon; EC = equivalent carbon; GD = gestation day; HEC = human equivalent concentration; HFAN = high flash aromatic naphtha; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; PPRTV = Provisional Peer-Reviewed Toxicity Value; p-RfC = provisional reference concentration; RfC = reference concentration; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

As shown in Table 7, the values of RfCs for fraction members show consistency across the fraction with respect to the toxicological effects exerted (most frequently neurological and developmental effects). The data show that an indicator chemical identifying effects on these targets would be reasonably anticipated to be representative of the effects of the fraction as a whole. Therefore, the compounds that resulted in the lowest RfCs for these effects were considered as the basis for surrogate selection (see Section 2.3).

### 6.2.1 Inhalation Noncancer Assessment Using the Indicator Chemical Method for the Aromatic Medium Carbon Range Fraction

If available analytical chemistry data do not identify concentrations of individual chemicals in this fraction, the lowest subchronic and chronic p-RfCs (0.2 mg/m^3^ and 0.06 mg/m^3^, respectively) for TMBs (0.2 and 0.06 mg/m^3^, respectively; see Table 7); these values are recommended as indicator chemicals for the aromatic medium carbon range fraction U.S. EPA (2016a). The RfCs for TMBs are based on neurological effects (decreased pain sensitivity), and available data generally support the nervous system as a target of the aromatic medium carbon compounds. Use of these values is anticipated to be protective for exposure to other constituents based on the available toxicological information (see Appendix B). However, users of the indicator chemical method should understand that there could be more uncertainty associated with the application of this toxicity value to the aromatic medium carbon range fraction than for its derivation in the IRIS assessment U.S. EPA (2016b) and application to individual TMBs in the environment.

The IRIS review of TMBs cited Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b) as the principal study for the subchronic and chronic RfCs. A summary of this study was provided in the preceding section (see Section 6.1). The POD_ADJ_ of 0.099 mg/L (described in the preceding section) was converted to a BMCL (HEC) of 18.15 mg/m^3^ based on the available PBPK model; this was used to derive subchronic and chronic RfCs for 1,2,4-TMB, which were applied to all TMBs (see Table 7). As indicated in the preceding section, confidence in the principal study was low to medium. Confidence in the inhalation database was also low to medium. Although acute, short-term, subchronic, and developmental inhalation toxicity studies in rats and mice are available, there were no chronic or developmental neurotoxicity studies. In addition, supporting studies (with respect to the critical effect) were primarily from the same research group. Taken together, confidence in the subchronic and chronic RfCs was also low to medium.

Previously, in the PPRTV TPH Mixtures document U.S. EPA (2009b), the HFAN subchronic and chronic p-RfCs were recommended for assessing noncancer hazards associated with inhalation route exposures to this fraction, based on a 2009 PPRTV assessment U.S. EPA (2009c). In 2016, the U.S. EPA IRIS Program published TMB subchronic and chronic p-RfCs of 0.2 and 0.06 mg/m^3^, respectively U.S. EPA (2016a), which are lower than the respective HFAN values of 1 and 0.1 mg/m^3^, respectively U.S. EPA (2009c) (see Table 7). Because these are IRIS values rather than PPRTVs, these IRIS single chemical values should be used in the indicator chemical approach rather than HFAN-based surrogate mixture approach. The 2009 TPH mixture assessment indicates that HFAN toxicity values are similar to values for other individual compounds in the fraction, which supports using HFAN as a surrogate for the fraction; however, the 2016 TMB values are much lower than the HFAN values and that logic is not applicable.

### 6.2.2 Alternative Inhalation Noncancer Assessment Using the Hazard Index Method for the Aromatic Medium Carbon Range Fraction

If the available analytical chemistry data quantify the concentrations of TMBs, n-propylbenzene, or isopropylbenzene separately from the remainder of the aromatic medium carbon range fraction, it is recommended that HQs for the individual chemicals with analytical data be calculated and an HI for the mixture be developed using the calculated HQs.

For subchronic inhalation exposures, the subchronic RfCs or p-RfCs for TMBs (0.2 mg/m^3^) or n-propylbenzene (1.0 mg/m^3^) can be used as the denominator in the HQ equations (see Table 7). In this alternative approach, the subchronic RfC for TMBs (0.2 mg/m^3^) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually.

For chronic inhalation exposures, the following chronic RfCs or p-RfCs can be used in the denominator of the HQ equations: TMBs (0.06 mg/m^3^), isopropylbenzene (0.4 mg/m^3^), and n-propylbenzene (1.0 mg/m^3^) (see Table 7). In this alternative approach, the chronic RfC for TMBs (0.06 mg/m^3^) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually. As stated in Section 6.2.1, in the U.S. EPA’s PPRTV TPH Mixtures document U.S. EPA (2009b), the HFAN subchronic and chronic p-RfCs were recommended for assessing noncancer hazards associated with inhalation route exposures to this fraction, based on a 2009 PPRTV assessment U.S. EPA (2009c). In 2016, the U.S. EPA IRIS Program published TMB subchronic and chronic p-RfCs of 0.2 and 0.06 mg/m^3^, respectively (U.S. EPA, 2016a), which are lower than the HFAN values of 1 and 0.1 mg/m^3^ U.S. EPA (2009c) (see Table 7). Because these are IRIS values rather than PPRTVs, the U.S. EPA has more confidence in using these IRIS single chemical values in an HI approach rather than the HFAN values in surrogate mixture approach.

## 6.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

Table 8 summarizes the noncancer health reference values for indicator chemicals used when available analytical data and exposure estimates are limited to either air concentrations of or oral exposure rates associated with the whole fraction. When analytical results, air concentrations, or exposure rate measures for individual compounds with reference values are available, then the hazards associated with these compounds can be assessed separately, using the HI approach and reference values reported in Tables 6 and 7.

Table 8 Summary of Noncancer Reference Estimates for Indicator Chemicals for Aromatic Medium Carbon Range (C9–C10; EC9–EC < 11) Fraction of Total Petroleum Hydrocarbons

Toxicity Type (units); Indicator Chemical | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UFc | Reference
Subchronic p-RfD (mg/kg-d); trimethylbenzenes | Rat/M | Neurotoxicity (decreased pain sensitivity) | 0.04 mg/kg-d | BMDL (HED)^a^ | 3.5 | 100 | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
Chronic p-RfD (mg/kg-d); trimethylbenzenes | Rat/M | Neurotoxicity (decreased pain sensitivity) | 0.01 mg/kg-d | BMDL (HED)^a^ | 3.5 | 300 | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
Subchronic p-RfC (mg/m^3^); trimethylbenzenes | Rat/M | Neurotoxicity (decreased pain sensitivity) | 0.2 mg/m^3^ | BMDL (HEC) | 18.15 | 100 | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)
Chronic p-RfC (mg/m^3^); trimethylbenzenes | Rat/M | Neurotoxicity (decreased pain sensitivity) | 0.06 mg/m^3^ | BMDL (HEC) | 18.15 | 300 | Korsak and Rydzynski (1996) as cited in U.S. EPA (2016b)

a Based on route-to-route extrapolation (inhalation to oral) using a modified PBPK model.

BMDL = benchmark dose lower confidence limit; HEC = human equivalent concentration; HED = human equivalent dose; M = male(s); PBPK = physiologically based pharmacokinetic; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; UFc = composite uncertainty factor.

## 6.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

Carcinogenicity assessments for mixtures and individual components of the aromatic medium carbon range fraction that have assessments are shown below in Table 9. For all components of the fraction, there are either inadequate data to assess carcinogenic potential (via the oral or inhalation routes of exposure), or the available studies have not been formally evaluated by the U.S. EPA, and the U.S. EPA has not estimated the cancer potency associated with the study results.

Table 9 Available Cancer Weight-of-Evidence Evaluations for Aromatic Medium Carbon Range Fraction (C9–C10, EC9–EC < 11)

Compound or Mixture | Cancer WOE | Source
Isopropylbenzene (C9, EC8.66) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (1997)
n-Propylbenzene (C9, EC8.94) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2009d)
1,3,5-Trimethylbenzene (C9, EC9.15) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2016a)
1,2,4-Trimethylbenzene (C9, EC9.36) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2016a)
tert-Butylbenzene (C10, EC9.36) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2012b)
sec-Butylbenzene (C10, EC9.57) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2012a)
1,2,3-Trimethylbenzene (C9, EC9.65) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2016a)
n-Butylbenzene (C10, EC9.96) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2010)
High flash aromatic naphtha (C9–C10) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2009c)

C = carbon; EC = equivalent carbon; WOE = weight of evidence.

While data on genotoxicity testing of compounds and mixtures in the aromatic medium carbon range fraction are limited, available information suggests little to no genotoxic potential (see Section 5).

## 6.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

None of the mixtures or constituents in this fraction had an oral slope factor (OSF) or inhalation unit risk (IUR) from IRIS, PPRTVs, HEAST, MassDEP, or TPHCWG. Thus, a provisional oral slope factor (p-OSF) or provisional inhalation unit risk (p-IUR) was not derived for the fraction (see Table 10).

Table 10 Summary of Cancer Risk Estimates for Aromatic Medium Carbon Range (C9–C10; EC9–EC < 11) Fraction of TPHs

Toxicity Type (units) | Species/Sex | Tumor Type | Cancer Risk Estimate | Principal Study
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^ | NDr

C = carbon; EC = equivalent carbon; NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor; TPH = total petroleum hydrocarbon.