# 5 MECHANISTIC CONSIDERATIONS AND GENOTOXICITY

Mechanistic information for health effects associated with exposure to compounds in the aromatic medium carbon range is limited. There is evidence that renal histopathology induced by isopropylbenzene in male rats reflects an alpha 2u-globulin (α2u-g)-specific nephropathy that is specific to male rats, and is therefore not an appropriate endpoint for human health risk assessment U.S. EPA (1997). Similar changes were noted in one study of an HFAN mixture U.S. EPA (2009c). Renal effects in studies of other fraction members were limited primarily to increases in kidney weight (see discussion of renal effects in Section 3.1). For isopropylbenzene, increases in kidney weight were unrelated to α2u-g-specific nephropathy, as they occurred in females as well as males [increased kidney weight in females was the critical effect for both the RfD and RfC for isopropylbenzene U.S. EPA (1997)]. Therefore, increases in renal weight associated with other fraction members does not necessarily result from α2u-g-specific nephropathy. In fact, there is no evidence for α2u-g-specific nephropathy among specific fraction member compounds other than isopropylbenzene (HFAN is a mixture of C8–C10 aromatics that can include isopropylbenzene).

Genotoxicity data for aromatic medium carbon range compounds primarily indicate little to no genotoxic potential. Almost all relevant mixtures or compounds were negative with or without metabolic activation in in vitro tests for point mutations in bacteria or mammalian cells U.S. EPA (2016a; OECD (2012a, b; U.S. EPA (2012b, 2011, 2009c, d; Oecd (2007; U.S. EPA (1997; Oecd (1994). The only exception was 1,2,3-TMB, which produced reverse mutations in Salmonella without, but not with, metabolic activation U.S. EPA (2016a). All three TMB isomers were at least weakly positive for sister chromatid exchange (SCE) in mice tested in vivo U.S. EPA (2016a). However, the larger C9 fraction to which TMB belongs was negative for SCE in Chinese hamster ovary (CHO) cells in vitro Oecd (2012b). Other tests of fraction members (including the TMB isomers) for clastogenicity (chromosomal aberrations [CAs] or micronucleus [MN] formation) in rodents in vivo or in rodent cells in vitro were negative or equivocal U.S. EPA (2016a; OECD (2012a, b; U.S. EPA (2012b; Oecd (2007; U.S. EPA (1997; Oecd (1994). By contrast, clastogenicity was reported for a commercial HFAN mixture in human lymphocytes with activation U.S. EPA (2009c). This HFAN mixture also was reported to produce deoxyribonucleic acid (DNA) damage in Escherichia coli without activation U.S. EPA (2009c). The only other finding relevant to DNA damage was equivocal evidence for unscheduled DNA synthesis (UDS) in rat hepatocytes by isopropylbenzene U.S. EPA (1997). There was also equivocal evidence for BALB/3T3 cell transformation by isopropylbenzene U.S. EPA (1997).