# 4 TOXICOKINETIC CONSIDERATIONS

Reviews of toxicokinetic information on aromatic medium carbon chain length hydrocarbons have been performed by McKee et al. (2015) and Infante and Bingham (2012). In general, these chemicals are well absorbed by oral and inhalation exposure and distributed widely throughout the body, with initial concentration in adipose tissue. Metabolism is efficient and occurs primarily via oxidation and conjugation of the alkyl side chains off the aromatic ring. These water-soluble metabolites are rapidly eliminated in the urine.

Compounds in the aromatic medium carbon range fraction are readily absorbed following oral exposure. F344 rats exposed to radiolabeled isopropylbenzene (cumene) by gavage showed maximum blood concentration levels 4 hours after dosing (the earliest time point sampled) at 33 mg/kg and 8–16 hours after dosing at 1,350 mg/kg U.S. EPA (1997). Based on recovery of urinary metabolites (time point not specified), absorption exceeded 70%. Absorption of p-isopropyltoluene (cymene) was at least 60–80% in rats and guinea pigs treated at 100 mg/kg and 52–74% in rats and various marsupial species treated at 50 or 200 mg/kg, based on urinary metabolites excreted within 48 hours U.S. EPA (2011). Absorption of n- and tert-butylbenzene was similarly found to exceed 66–81% in rabbits U.S. EPA (2012b). More than 99% of an orally administered dose of 1,2,4-TMB was absorbed (and subsequently eliminated) within 24 hours in rats McKee et al. (2015).

Absorption following inhalation exposure is rapid and extensive. Isopropylbenzene was detected in the blood of F344 rats within 5 minutes of the start of inhalation exposure U.S. EPA (1997). Based on recovery of urinary metabolites (time point not specified), absorption exceeded 70% in rats exposed to 100, 500, or 1,500 ppm isopropylbenzene U.S. EPA (1997). Mean respiratory tract retention was reported to be 50% (45–64%) in volunteers exposed to isopropylbenzene at 240, 480, or 720 mg/m^3^ for 8-hour periods U.S. EPA (1997). Respiratory retentions for the three TMB isomers were approximately 70% in human subjects exposed at 5–150 mg/m^3^ for 8 hours and 60% in subjects exposed to 2–25 ppm (10–125 mg/m^3^) for 2 hours while performing light activity McKee et al. (2015; Infante and Bingham (2012). Consistent with these results, measured blood-air partition coefficients for these compounds are high in humans and laboratory animals. Human blood-air partition coefficients are 47 for n-propylbenzene and 37 for isopropylbenzene U.S. EPA (2009d). Blood-air partition coefficients for TMB isomers (1,2,4-TMB, 1,2,3-TMB, and 1,3,5-TMB, respectively) are 59.1, 66.5, and 43.0 in humans and 57.7, 62.6, and 55.7 in rats U.S. EPA (2016b).

Compounds in the aromatic medium carbon range fraction are widely distributed in the body after inhalation or oral exposure. Studies with isopropylbenzene, TMB isomers, and tert-butylbenzene all showed elevated concentrations of the administered chemical in fat (also stomach by oral route) >> kidney > liver > brain >blood in rats after exposure, regardless of route U.S. EPA (2016a, 2012b, 1997). Levels in fat were 10- to 100-fold higher than in other tissues. Modeling of tissue-air partition coefficients suggests that tissue distribution in humans would be similar to that seen in rats U.S. EPA (2016a; McKee et al. (2015). Due to the high lipophilicity of these chemicals, it has been estimated that 85% of alkylbenzene in the blood is bound to red blood cells (RBCs) U.S. EPA (2012b). TMBs and tert-butylbenzene have been shown to cross the placenta U.S. EPA (2016a; Infante and Bingham (2012).

Similar to absorption, metabolism of aromatic medium carbon range compounds is rapid and extensive. Metabolism proceeds primarily by oxidation of side chains on the aromatic ring to form the corresponding alcohols and carboxylic acids, followed by conjugation with glycine (hippuric acid), cysteine (mercapturic acid), glucuronic acid, or sulfate U.S. EPA (2016a; McKee et al. (2015; U.S. EPA (2012b, 2011, 2009d, 1997). Example chemicals (and principal metabolites) are isopropylbenzene (2-phenyl-2-propanol and its glucuronide and sulfate conjugates) U.S. EPA (1997), n-propylbenzene (glucuronides of ethylphenyl carbinol and benzyl methyl carbinol) U.S. EPA (2009d), 1,2,4-TMB (3,4-dimethylhippuric acid) U.S. EPA (2016a), 1,3,5-TMB (3,5-dimethylhippuric acid) McKee et al. (2015), tert-butylbenzene (2,2-dimethyl-2-phenylethyl glucuronide) U.S. EPA (2012b), and isopropyltoluene (2-[4-methylphenyl]propan-1-ol, 2-[4-methylphenyl]propan-2-ol) U.S. EPA (2011). Oxidation of the aromatic ring to form the corresponding phenol is a minor metabolic pathway for at least some of these chemicals U.S. EPA (2016a; Infante and Bingham (2012; U.S. EPA (2011). Where data in multiple species are available, metabolic profiles are similar in rats, rabbits, and humans U.S. EPA (2016a; McKee et al. (2015). Metabolism of aromatic medium carbon range compounds occurs in the liver, lung, and other tissues [e.g., kidney, adrenal, brain, and bone marrow U.S. EPA (2012b, 2009d, 1997)]. Several of these compounds have been shown to induce metabolic enzymes, and therefore, their own metabolism McKee et al. (2015; U.S. EPA (2012b, 2009d). There is some experimental evidence for saturation of metabolism at high exposure levels: blood concentrations of 4-ethyltoluene in rats were 10-fold higher after a single 6-hour exposure at 1,000 mg/m^3^ than at 250 mg/m^3^ [fourfold difference in exposure concentration McKee et al. (2015)].

Metabolites of aromatic medium carbon range compounds are water soluble and rapidly excreted in the urine McKee et al. (2015; U.S. EPA (2012b). Less than 1% of the absorbed fraction remained in the body 72 hours after inhalation exposure of isopropylbenzene at 1,200 ppm to rats U.S. EPA (1997). Similarly, >99% of an oral dose of 1,2,4-TMB was eliminated as metabolites in the urine within 24 hours after dosing in rats McKee et al. (2015). In studies of p-isopropyltoluene, at least 60–80% of an oral dose in rats and guinea pigs and 52–74% of an oral dose in rats and various marsupial species was excreted as metabolites in the urine within 48 hours U.S. EPA (2011). Small amounts of unchanged parent compound may also be found in the urine U.S. EPA (2016a, 2012b). Following inhalation exposure, unchanged parent compound may be exhaled via the lungs. Human subjects who retained 60% of inhaled TMB in the lung subsequently exhaled approximately 30% of the retained material Infante and Bingham (2012). In one human study, elimination of 1,3,5-TMB via breath was biphasic, with an initial half-life of 60 minutes and a terminal half-life of 600 minutes U.S. EPA (2016a; McKee et al. (2015). Breath concentrations of 1,3,5-TMB in this study returned to pre-exposure levels within 24 hours McKee et al. (2015).