# 3 REVIEW OF POTENTIALLY RELEVANT DATA

## 3.1 NONCANCER EVIDENCE

Compound-specific IRIS and PPRTV documents, supplemented by the literature search findings and the review articles described above [particularly McKee et al. (2015)] were assessed to evaluate available noncancer data for the aromatic medium carbon range fraction compounds. Critical effects identified with existing toxicity values include neurological, hepatic, renal, body-weight, hematological, endocrine, respiratory, and developmental effects. Appendix B summarizes the evidence provided by human and experimental animal studies of noncancer health outcomes. Table 5 presents an overview of the human and animal data available to evaluate the primary toxicological endpoints identified for the fraction (neurological, hepatic, renal, body weight, hematological, endocrine, respiratory, and developmental). As Table 5 shows, both oral and inhalation data available to assess consistency in effects across members of the fraction are limited. There are no dependable human or animal data for at least three members of the fraction (n-propylbenzene, and tert- and sec-butylbenzene). There are oral or inhalation body-weight data for 11 members, and there are neurotoxicity endpoint data available for 9 members. For all other primary toxicological endpoints, there are oral or inhalation data for 5–7 members of the fraction. Most of the animal data are from inhalation toxicity studies. Comprehensive systemic toxicity was evaluated in rats and mice in subchronic and chronic inhalation studies for one member of the fraction (isopropylbenzene). In general, studies ranged in duration from 4 to 18 weeks; several of these studies (e.g., DEBs and TMBs) evaluated only neurological endpoints. Developmental inhalation toxicity studies were available for four members of the fraction (isopropylbenzene, 1,3,5- and 1,2,4-TMB, and HFAN). Finally, unless otherwise specified, the term “significant,” used throughout the document, refers to statistical significance at a p-value of < 0.05.

Table 5 Overview of Human and Animal Data Availability for Evidence Integration^a,^ ^b^

CASRN | Name | C | EC | Neurological | Hepatic | Renal | Body Weight | Hematological | Endocrine | Respiratory | Developmental
98-82-8 | Isopropylbenzene | 9 | 8.66 | I | I | I, O | I | I | I | I | I
103-65-1 | n-Propylbenzene ^c^ | 9 | 8.94
622-96-8 | 1-Methyl-4-ethylbenzene | 9 | 9.07 | | | | I | | | I
108-67-8 | 1,3,5-Trimethylbenzene | 9 | 9.15 | H, I | O | O | O, I | H, O | | H | I
95-63-6 | 1,2,4-Trimethylbenzene | 9 | 9.36 | H, I | I | I | I | H, I | I | H, I | I
98-06-6 | tert-Butylbenzene ^c^ | 10 | 9.36
135-98-8 | sec-Butylbenzene ^c^ | 10 | 9.57
526-73-8 | 1,2,3-Trimethylbenzene | 9 | 9.65 | H, I | I | I | I | H, I | I | H, I
141-93-5 | 1,3-Diethylbenzene | 10 | 9.91 | O | | | O
105-05-5 | 1,4-Diethylbenzene | 10 | 9.96 | O | O | O | O | O | | | O
104-51-8 | n-Butylbenzene | 10 | 9.96 | | O | O | O | | O | | O
135-01-3 | 1,2-Diethylbenzene | 10 | 9.96 | O | | | O
64742-95-6 | HFAN | 9–10 | NA | I | O, I | O, I | O, I | O, I | O | | O, I
NA | Diethylbenzenes (mixture) | 10 | NA | O, I | | | O, I

a Includes human and animal studies meeting inclusion criteria. Bolded compounds and mixtures have at least one oral or inhalation toxicity value available (see Table 4).

b Compounds are arranged by increasing EC number.

c In the absence of human or animal data, screening toxicity values were derived using appropriate analogue chemicals (ethylbenzene and isopropylbenzene) in the PPRTV assessments of these compounds.

C = carbon; EC = equivalent carbon; H = human data; HFAN = high flash aromatic naphtha; I = animal inhalation studies; NA = not applicable; O = animal oral studies.

Critical effects used to derive oral or inhalation toxicity values for the aromatic medium carbon range fraction compounds and mixtures include neurological effects (decreased pain sensitivity), hepatic toxicity (hepatocellular hypertrophy), renal toxicity (increased kidney weight and histopathology), decreased body weight, hematological toxicity, endocrine system toxicity, and developmental toxicity (decreased fetal/pup body weights and delayed skeletal ossification). The available data for most of the aromatic medium carbon range compounds and mixtures are limited for endpoints other than body weight and are altogether absent for three members of the fraction (n-propylbenzene, and tert- and sec-butylbenzene). A majority of toxicity data are from subchronic studies of the inhalation route of exposure, and few compounds have been tested for toxicity following chronic oral or inhalation exposure.

Based on review of the available oral and inhalation toxicity data, there is evidence that several members of the fraction, and especially TMBs and DEBs, can induce neurological effects; however, most of the compounds in the fraction have not been evaluated for sensitive measures of neurological function. Information across half of the compounds (oral and inhalation exposure) composing the fraction suggests that aromatic medium carbon range fraction compounds and mixtures can induce hepatic effects in the form of increased liver weight, often accompanied by histological effects (most frequently hepatocellular hypertrophy via oral exposure). Similarly, data show that several members of the aromatic medium carbon range fraction induce significant increases in relative kidney weight after oral or inhalation exposure; this effect was seen (infrequently) in conjunction with serum chemistry changes (i.e., increased blood urea nitrogen [BUN] after oral exposure to 1,4-DEB) and in the absence of corresponding histological changes (other than rat-specific male nephropathy). Data on body-weight effects after oral and inhalation exposure to a variety of aromatic medium carbon range fraction compounds and mixtures indicate that members of the fraction can be expected to induce body-weight reductions generally at high doses.

The available data are not considered adequate to evaluate consistency in effects or potencies across fraction members for hematological or endocrine effects. Because there are data for only five compounds, data are insufficient to determine if respiratory effects are consistently associated with inhalation exposure to members of the aromatic medium carbon range fraction (there are no oral exposure data on respiratory effects). Finally, data from oral and inhalation developmental toxicity studies consistently identify decreased fetal body weights and delays in skeletal development for several members of the aromatic medium carbon range fraction.

## 3.2 CANCER EVIDENCE

### 3.2.1 Human Studies

No human studies were available to address the carcinogenic potential of the TMB isomers or other members of the aromatic medium carbon range fraction by any route of exposure.

### 3.2.2 Animal Studies—Oral

A single carcinogenicity study in rats orally exposed to 1,2,4-TMB for 104 weeks was identified Clark et al., 1989 as cited in U.S. EPA (2009c). The only noteworthy finding was a nonsignificant increase in the incidence of neuroesthesioepitheliomas (3/100 treated animals based on the combined sexes compared to 0/100 controls). Several study limitations were apparent, including use of one rodent species, treatment at a single dose level (800 mg/kg-day), and lack of quantitative mortality data (“slight” or “intermediate” reductions in survival were reported). Therefore, the available oral data are not sufficient to adequately assess the carcinogenic potential of 1,2,4-TMB (or other members of the aromatic medium carbon range fraction).

### 3.2.3 Animal Studies—Inhalation

No neoplasms were reported in rats treated with HFAN for 12 months Clark et al., 1989 as cited in U.S. EPA (2009c).

New studies identified in the PubMed searches included a 105-week chronic toxicity/carcinogenicity study of isopropylbenzene in rats and mice by the National Toxicology Program Ntp (2009). Statistically significantly increased incidences of respiratory epithelial adenomas of the nose in both sexes and renal adenoma or carcinoma (combined) in males were observed in rats. Increased interstitial cell adenomas were also reported in the male testis; however, the NTP report stated that these were possibly related to isopropylbenzene exposure. While the incidence of interstitial cell adenomas reported in the highest dose group in the male rats was statistically significantly increased compared to the control group and there was a positive trend in the incidences reported among all exposed groups, the incidence in the high-dose group was within the range for historical chamber controls when studies with all exposure routes were considered. Interstitial cell hyperplasia and adenoma are common proliferative lesions in F344/N rats (i.e., the test species) and reportedly will develop in nearly all male rats of this strain that are allowed to complete their natural life span Ntp (2009). In mice, the incidences of alveolar/bronchiolar adenomas were significantly increased in both sexes; increased incidences of hemangiosarcomas and follicular cell adenomas in males^4^ (possibly related to exposure) and hepatocellular adenomas or carcinomas in females also were reported. Based on these data, the NTP concluded that there was clear evidence of carcinogenicity in male rats and male and female mice, and some evidence of carcinogenic activity in female rats.

No studies evaluating carcinogenicity were available for other members of the aromatic medium carbon range fraction.

### 3.2.4 Summary of Cancer Evidence

Few data are available to assess the carcinogenic potential of compounds and mixtures in the aromatic medium carbon range fraction. No human data were identified. Animal data are limited to 1,2,4-TMB and isopropylbenzene. Several limitations were identified in the carcinogenicity study of 1,2,4-TMB. Only data from a newly identified study for isopropylbenzene Ntp (2009) are considered adequate to assess carcinogenic potential of individual fraction members. At this time, U.S. EPA has not formally evaluated the Ntp (2009) study and has not estimated the cancer potency associated with the study results.

4 NTP described the increased incidence of hemangiosarcomas in males as “equivocal;” these tumors were observed only in the highest dose group. The incidences of follicular cell adenoma increased with a statistically significant positive trend in male mice; however, the incidence in the highest dose group was at the upper end of the historical ranges for chamber controls in inhalation studies and for historical controls (all exposure routes). NTP described these increases to be “possibly related to cumene exposure.”