# 2 SUMMARY OF TOXICITY AND DOSE-RESPONSE ASSESSMENT APPROACH

Toxicity and dose-response assessment for the aromatic medium carbon range fraction entailed five basic steps, outlined here and described in more detail below. Mixtures and compounds that met structural criteria (see Section 1.1) and had available toxicity values from designated sources were identified. The dose-response assessment for the fraction can include selection of a health reference value from an indicator chemical. Alternatively, if exposure measurement data are available for component chemicals, those health reference values from component chemicals with existing toxicity values can be used to apply the HI approach.

In Step 1 and Step 2 of the assessment, literature searches were performed for the mixtures and compounds with toxicity values and for other mixtures and compounds that are relevant to the fraction. Searches date-limited to assessments published from 2009 forward (e.g., Agency for Toxic Substances and Disease Registry [ATSDR], Integrated Risk Information System [IRIS]) were conducted in February 2018, and updated most recently in August 2021. The start date of 2009 was selected to determine whether new information suggested that toxicity values for mixtures or compounds relevant to the fraction should be updated from those identified in the U.S. EPA (2009b) PPRTV for complex mixtures of aliphatic and aromatic hydrocarbons. Step 3 in the assessment involved searching PubMed for new noncancer toxicity data on compounds and mixtures lacking either Integrated Risk Information System (IRIS) oral or inhalation toxicity values. These literature searches were conducted in February 2018, updated in August 2021, and were date-limited to studies published from 2007 forward, in order to capture studies that were published since the searches performed in U.S. EPA (2009b). Step 4 in the assessment involved searching recent comprehensive reviews on the toxicity of petroleum components or classes of compounds relevant to the fraction, as well as Organisation for Economic Co-operation and Development (OECD) Screening Information Data Set (SIDS) assessments^3^ and the Petroleum High Production Volume (HPV) Testing Group website, to identify other mixtures or compounds within this carbon range with existing toxicity data that may inform hazard identification for the fraction. Step 5 of the assessment involved informal searches of PubMed to identify mixtures that met structural criteria of the fraction and had toxicity data available. Toxicity data criteria included human studies of any duration by oral, inhalation, and dermal exposure, and animal studies of oral or inhalation exposure lasting at least 28 days (or any duration of gestational exposure). Mixture toxicity data were considered relevant only if the mixture composition under study was quantitatively defined to enable assessment of relevance to the fraction. Figure 2 shows a schematic depiction of the process, and further detail is provided below.

Figure 2 Selection of Compounds and Mixtures for Aromatic Medium Carbon Range Fraction Hazard Identification and Dose-Response Assessment

Compounds and mixtures relevant to the aromatic medium carbon range fraction with available toxicity values or data were identified in a five-step process. Table 3 lists individual compounds and mixtures and links them to their corresponding identification source during the literature search process. Table 3 also indicates compounds with available toxicity values, or in the absence of toxicity values, available toxicity data.

ATSDR = Agency for Toxic Substances and Disease Registry; C = carbon; EC = equivalent carbon; HPV = High Production Volume; IRIS = Integrated Risk Information System; OECD = Organisation for Economic Co-operation and Development; PPRTV = Provisional Peer-Reviewed Toxicity Value; RfC = reference concentration; RfD = reference dose; SIDS = Screening Information Data Set.

Timeline Description automatically generated

## 2.1 IDENTIFICATION OF RELEVANT MIXTURES AND COMPOUNDS WITH TOXICITY VALUES

Step 1 (see Figure 2) in the assessment of the toxicity for the aromatic medium carbon range fraction was to identify constituents of the fraction that have existing toxicity values from any of the sources considered for the U.S. EPA (2009b) PPRTV assessment for complex mixtures of aliphatic and aromatic hydrocarbons (these included IRIS, PPRTVs, ATSDR Minimal Risk Levels [MRLs], Massachusetts Department of Environmental Protection [MassDEP], Total Petroleum Hydrocarbon Criteria Working Group [TPHCWG], and Health Effects Assessment Summary Tables [HEAST]). Of these sources, only IRIS, PPRTVs, and ATSDR MRLs have been updated since 2009, so only these sources were consulted for toxicity values. Based on the U.S. EPA’s previous assessments and assessment activities as well as those relevant chemicals reviewed by the MassDEP MassDep (2003) or TPHCWG Edwards et al. (1997), the U.S. EPA compiled an initial list of 12 chemicals and 1 mixture (i.e., high flash aromatic naphtha [HFAN]). [See full list in Appendix A and description of approach and results in Wang et al. (2012).] Table 3 lists the chemicals and mixtures for which PubMed searches were performed, published toxicity data were identified, and toxicity values were identified. At least one updated subchronic or chronic oral or inhalation reference value was available for eight chemicals (isopropylbenzene, n-propylbenzene, 1,3,5-trimethylbenzene [TMB], 1,2,4-TMB, 1,2,3-TMB, tert-butylbenzene, sec-butylbenzene, and n-butylbenzene), and one mixture (HFAN).

Table 3 Chemicals and Mixtures Identified in Literature Searches

CASRN | Chemical Name | Literature Search Identification Source | PubMed Searches Performed | Toxicity Values Identified | Toxicity Data Identified
526-73-8 | 1,2,3-Trimethyl-benzene | Initial list of 12 compounds + 1 mixture^a,^ ^b,^ ^c^ | | X
95-63-6 | 1,2,4-Trimethyl-benzene | Initial list of 12 compounds + 1 mixture^a,^ ^b,^ ^c^ | | X
135-01-3 | 1,2-Diethylbenzene | Recent reviews of petroleum toxicity^d,^ ^e^ | | | X
108-67-8 | 1,3,5-Trimethyl-benzene | Initial list of 12 compounds + 1 mixture^a,^ ^b,^ ^c^ | | X
141-93-5 | 1,3-Diethylbenzene | Recent reviews of petroleum toxicity^d,^ ^e^ | | | X
105-05-5 | 1,4-Diethylbenzene | Recent reviews of petroleum toxicity^d,^ ^e^ | | | X
620-14-4 | 1-Methyl-3-ethyl-benzene | Initial list of 12 compounds + 1 mixture^a^ | X
622-96-8 | 1-Methyl-4-ethylbenzene | Initial list of 12 compounds + 1 mixture^a,^ ^f,^ ^g^ | X | | X
535-77-3 | 1-Methyl-3-isopropylbenzene | Initial list of 12 compounds + 1 mixture^a^ | X
Various | Alkylbenzenes (various) | PubMed searches^f,^ ^h^ | X | | X
25340-17-4 | Diethylbenzene mixture | OECD SIDS^i^ | | | X
64742-95-6, 88845-25-4, and 64742-94-5 | High flash aromatic naphtha | Initial list of 12 compounds + 1 mixture^a,^ ^b^ | X | X
538-93-2 | Isobutylbenzene | Initial list of 12 compounds + 1 mixture^a^ | X
98-82-8 | Isopropylbenzene | Initial list of 12 compounds + 1 mixture^a,^ ^b,^ ^c^ | | X
104-51-8 | n-Butylbenzene | Initial list of 12 compounds + 1 mixture^a,^ ^b^ | X | X
103-65-1 | n-Propylbenzene | Initial list of 12 compounds + 1 mixture^a,^ ^b^ | X | X
Various | Naphtha solvent | PubMed searches^f,^ ^j^ | X | | X
99-87-6 | p-Isopropyltoluene | Updated PPRTV, IRIS, and ATSDR MRL databases^k^ | | | X^l^
135-98-8 | sec-Butylbenzene | Initial list of 12 compounds + 1 mixture^a,^ ^b^ | X | X
98-06-6 | tert-Butylbenzene | Initial list of 12 compounds + 1 mixture^a,^ ^b^ | X | X

a U.S. EPA developed the initial list of 12 chemicals and 1 mixture relevant to the aromatic medium carbon range. The list included all individual hydrocarbons considered previously by the U.S. EPA’s STSC in the evaluation of hydrocarbons, as well as all those with toxicity data reviewed by the MassDEP MassDep (2003) or TPHCWG Edwards et al. (1997).

b At least one updated (since 2009) subchronic oral or inhalation reference value was available for these compounds following searches of the IRIS, PPRTV, and ATSDR databases.

c Because these compounds had IRIS, PPRTV, or ATSDR toxicity values for both oral and inhalation routes, no additional literature searches were performed.

d These compounds/mixtures were identified in McKee et al. (2015), a recent review of petroleum toxicity.

e Toxicity data for these compounds were found in Gagnaire et al. (1990).

f These compounds were identified in PubMed searches date-limited to studies published from 2007 forward, conducted in February 2018.

g Toxicity data for this compound were found in Swiercz et al. (2000).

h Human olfaction data for these compounds were found in Cometto-Muniz and Abraham (2009).

i Toxicity data for this mixture were found in Oecd (2007).

j A human case report for this mixture was found in Magdalan et al. (2009).

k During review of the updated IRIS, PPRTV, and ATSDR MRL databases, these compounds were identified in the PPRTV database as meeting structural criteria for inclusion and having toxicity assessments.

l This compound was not considered relevant to this assessment because this compound does not typically occur or co-occur with petroleum contamination. The U.S. EPA (2011) PPRTV for isopropyltoluene identified no studies investigating health effects following oral exposures for short-term, subchronic, or chronic durations; further, no developmental or reproductive oral exposure studies were identified. The PPRTV reported data on p-isopropyltoluene-induced toxicity in animals exposed orally limited to a single-dose, acute toxicity study that reported depression, coma, bloody lacrimation, diarrhea, irritability, and scrawny appearance in treated Osbourne-Mendel rats. The PPRTV identified one subchronic inhalation study and two acute inhalation studies; these reported mortality in mice, but not in rats or guinea pigs. A necropsy in the mice revealed hyperemic lungs, mottled liver, and pale kidney.

ATSDR = Agency for Toxic Substances and Disease Registry; IRIS = Integrated Risk Information System; MassDEP = Massachusetts Department of Environmental Protection; MRL = minimal risk level; OECD = Organisation for Economic Co-operation and Development; PPRTV = provisional peer-reviewed toxicity value; SIDS = Screening Information Data Set; STSC = Superfund Technical Support Center; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group; U.S. EPA = U.S. Environmental Protection Agency.

In Step 2 (see Figure 2), all existing chemicals in the IRIS, PPRTV, and ATSDR MRL databases were searched to determine whether they included any other compounds or mixtures (not on the initial list) meeting the structural criteria for inclusion (C9–C10 and EC9–EC < 11 aromatics). Searches of the IRIS and ATSDR databases did not identify any additional compounds, but review of the PPRTV database identified one additional compound with a toxicity assessment (but no health risk values), p-isopropyltoluene (p-cymene). Review of the Petroleum Hydrocarbon Criteria Working Group’s (1998) Selection of Representative TPH Fractions Based on Fate and Transport Considerations Gustafson et al. (1997b) indicated that this compound typically does not occur or co-occur with petroleum contamination, a finding further confirmed by Ullmann’s Encyclopedia of Industrial Chemistry Eggersdorfer (2012). Therefore, p-isopropyltoluene was not considered relevant to the assessment of the aromatic medium carbon range fraction and is not discussed further. Table 4 shows the health risk values available for the eight relevant compounds and the HFAN mixture.

Table 4 Summary of Available Toxicity Values for Mixtures and Constituents of Aromatic Medium Carbon Range (C9–C10, EC9–EC < 11) Fraction^a^

CASRN | Name | C | EC | Oral Reference Dose (mg/kg-d) | | Inhalation Reference Concentration (mg/m^3^)
CASRN | Name | C | EC | Subchronic | Chronic | Subchronic | Chronic
98-82-8 | Isopropylbenzene | 9 | 8.66 | – | 0.1 (IRIS) | – | 0.4 (IRIS)
103-65-1 | n-Propylbenzene | 9 | 8.94 | 0.1^b^ (PPRTV^*^) | 0.1^b^ (PPRTV^*^) | 1^b^ (PPRTV^*^) | 1^b^ (PPRTV^*^)
108-67-8 | 1,3,5-TMB | 9 | 9.15 | 0.04 (IRIS) | 0.01 (IRIS) | 0.2 (IRIS) | 0.06 (IRIS)
95-63-6 | 1,2,4-TMB | 9 | 9.36 | 0.04 (IRIS) | 0.01 (IRIS) | 0.2 (IRIS) | 0.06 (IRIS)
98-06-6 | tert-Butylbenzene | 10 | 9.36 | 0.1^c^ (PPRTV^*^) | 0.1^c^ (PPRTV^*^) | – | –
135-98-8 | sec-Butylbenzene | 10 | 9.57 | 0.1^c^ (PPRTV^*^) | 0.1^c^ (PPRTV^*^) | – | –
526-73-8 | 1,2,3-TMB | 9 | 9.65 | 0.04 (IRIS) | 0.01 (IRIS) | 0.2 (IRIS) | 0.06 (IRIS)
104-51-8 | n-Butylbenzene | 10 | 9.96 | 0.1 (PPRTV) | 0.05 (PPRTV) | – | –
64742-95-6 | HFAN | 9–10 | NA | 0.3 (PPRTV^*^) | 0.03 (PPRTV^*^) | 1 (PPRTV) | 0.1 (PPRTV)

a Toxicity values shown were selected from the following sources in order of preference: IRIS, PPRTV, ATSDR, HEAST, MassDEP, or TPHCWG. None of the mixtures or constituents in this fraction has an OSF or IUR.

b Based on the identification of ethylbenzene (CASRN 100-41-4) as an appropriate analogue chemical.

c Based on the identification of isopropylbenzene (CASRN 98-82-8) as an appropriate analogue chemical.

* Screening provisional toxicity value. Screening values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening values are derived when the data do not meet all requirements for deriving a provisional toxicity value. Screening values are derived using the same methodologies and undergo the same development and review processes (i.e., internal and external peer review, etc.) as provisional values; however, there is generally more uncertainty associated with these values.

ATSDR = Agency for Toxic Substances and Disease Registry; C = carbon; EC = equivalent carbon; HEAST = Health Effects Assessment Summary Tables; HFAN = high flash aromatic naphtha; IRIS = Integrated Risk Information System; IUR = inhalation unit risk; MassDEP = Massachusetts Department of Environmental Protection; NA = not applicable; OSF = oral slope factor; PPRTV = provisional peer-reviewed toxicity value; TMB = trimethylbenzene; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group.

## 2.2 IDENTIFICATION OF OTHER RELEVANT TOXICITY DATA

Among the 12 compounds and 1 mixture on the initial list determined to be relevant to the fraction, both oral and inhalation IRIS toxicity values were available for four compounds (isopropylbenzene and the three TMB isomers). Therefore, these compounds were not included in the comprehensive literature searches. In Step 3 (see Figure 2), literature searches were conducted in PubMed to identify any new studies that could fill data gaps for the remaining eight compounds and one mixture. The literature searches were conducted in February 2018, were most recently updated in August 2021, and were date-limited to studies published from 2007 forward, in order to capture studies that were published since the searches performed for the 2009 PPRTV assessment for complex TPH mixtures. A summary of the literature search strategy is provided in Appendix A. As detailed in the appendix, studies considered relevant to hazard identification included animal studies using inhalation or oral exposure routes, in which exposures continued for at least 28 days (or any duration of gestational exposure), at least one health outcome was assessed, and an untreated or vehicle control group was included. Human studies of any duration in which exposure was known or presumed to be through oral, inhalation, or dermal routes and at least one health outcome was assessed were considered relevant.

The updated literature search identified two human studies: an acute human olfaction study of alkylbenzenes Cometto-Muniz and Abraham (2009) and a case report of exposure to naphtha solvent Magdalan et al. (2009). The only relevant animal study that was identified in the updated literature search was a 4-week study of 1-methyl-4-ethylbenzene Swiercz et al. (2000). No relevant reviews or secondary sources were identified.

In Step 4 (see Figure 2), to determine whether additional relevant compounds or mixtures had been tested for repeat-dose and/or reproductive/developmental toxicity since 2007, recent reviews of petroleum toxicity McKee et al. (2015; Infante and Bingham (2012; OECD (2012a, b, 2007) and the Petroleum HPV Testing Group website were searched. Mixtures considered relevant to the fraction met the following criteria (see Figure 2):

1. at least 90% of the mixture consisted of identified compounds within the C9–C10 and EC9–EC < 11 ranges.
2. 99% of the mixture consisted of aromatic compounds (≤1% aliphatic).
3. the mixture had been tested in animals in at least one repeat-dose (≥28 days) or reproductive/developmental toxicity study using inhalation or oral exposure routes and including an untreated or vehicle control group.
4. human mixture studies of any duration by oral, inhalation, and dermal exposure, and animal studies of oral or inhalation exposure lasting at least 28 days (or any duration of gestational exposure).

Using the same criteria, in Step 5, PubMed searches were conducted to identify mixtures with relevant toxicity data.

None of the mixtures described on the Petroleum HPV Testing Group website met these criteria. Oecd (2007) described toxicity data on a commercial diethylbenzene (DEB) mixture that met these criteria. Thus, including HFAN, toxicity data for two mixtures were considered potentially relevant to the assessment of the aromatic medium carbon fraction. HFAN consists of TMB and ethyltoluene isomers; by definition, it must contain a combined total of 75% TMB and ethyltoluene isomers (of which at least 22% is ethyltoluene and at least 15% is TMB) U.S. EPA (2009c). Commercial DEB typically contains 60–65% 1,3-DEB, 27–30% 1,4-DEB, and 4–5% 1,2-DEB Oecd (2007). No further detail on the chemical compositions of these mixtures was available in the sources reviewed.

Searching the review by McKee et al. (2015) resulted in the identification of three additional compounds that met structural criteria and had toxicity data that met inclusion criteria (see Figure 2): 1,2-, 1,3-, and 1,4-DEB. The three DEB isomers were tested for neurotoxicity in a study of rats exposed orally for 10 weeks Gagnaire et al. (1990). No other mixtures or compounds with toxicity data were identified. Human and animal studies that met criteria outlined above were reviewed to support selection of surrogates for the aromatic medium carbon range fraction toxicity values.

## 2.3 METHODS FOR INDICATOR CHEMICAL SELECTION

Only compounds or mixtures with at least one U.S. EPA or ATSDR toxicity value (see Table 4) were to be considered for use as potential indicator chemicals (or indicator mixtures) for derivation of the fraction-specific toxicity values; however, no ATSDR toxicity values were identified. Toxicity data for other compounds that did not have toxicity values were used for hazard identification and to assess consistency in effects and potency across the components of the fraction. The method for selecting indicator chemicals was adapted from the 2009 complex TPH mixtures document U.S. EPA (2009b). First, mixtures consisting of fraction component chemicals were preferred over individual compounds, provided that the mixture study was adequate and the mixture exhibited in vivo toxic effects similar to those exhibited by the individual fraction components. If suitable mixture data were lacking, a representative compound exhibiting in vivo toxic effects and potency similar to those exhibited by other compounds in the fraction was chosen. If the components of the fraction varied widely in toxic effects or potency, the toxicity value for the most potent component (i.e., the component with lowest reference value) was selected as an indicator chemical for the fraction. Finally, if toxicity values were available for many or most of the individual compounds in a fraction, and these compounds are typically monitored at sites of hydrocarbon contamination, then a component approach would be considered.

## 2.4 DEVELOPMENT OF EXPOSURE-RESPONSE ARRAYS

In order to assess consistency in effects and potency across the components of the fraction, experimental data from compound-specific IRIS and PPRTV documents and primary data sources (identified from literature searches) were used to create exposure-response arrays provided in Appendix B. Data were extracted only from certain studies (i.e., studies that provided dose-response data enabling the identification of no-observed-adverse-effect levels [NOAELs] and lowest-observed-adverse-effect levels [LOAELs]). Target-organ-specific NOAELs and LOAELs were determined using the following methodology.

1. Whenever possible, NOAELs and LOAELs were identified from existing IRIS or PPRTV assessments. For chemicals in which both types of assessments were available, preference was given to IRIS (in accordance with U.S. EPA Office of Superfund Remediation and Technology Innovation [OSRTI] hierarchy of human health toxicity values for Superfund assessments). In general, these assessments explicitly identified NOAEL and LOAEL values only for the most sensitive target of toxicity, so characterization of additional adverse effect levels allowed for a comprehensive comparison of toxic effects across additional endpoints and tissues.
2. All other target-organ-specific effect levels (i.e., for targets other than the most sensitive target identified in IRIS or PPRTV assessments, and all targets evaluated in newly identified studies) were determined using scientific judgment, taking into consideration factors such as statistical significance (at a p-value < 0.05), biological significance (e.g., a greater than or equal to 10% increase in liver weight), magnitude and direction of change, and study quality. In the case of chemicals with existing IRIS or PPRTV assessments, NOAELs and LOAELs could often be identified from existing study summaries.

Dose-response data were presented in exposure-response arrays by health outcome and exposure route (see Appendix B). From left to right, compounds exhibiting an effect are shown before those not exhibiting an effect, to facilitate identification of patterns. Within the group exhibiting an effect, compounds are ordered from lowest LOAEL to highest. For compounds that do not exhibit an effect, NOAELs in the arrays are ordered by EC number (low to high from left to right), with mixtures shown last. Both administered doses and exposure concentrations reported in the arrays and in text reflect time-weighted average (TWA) exposures, to facilitate comparisons across studies and compounds. Consistency across the fraction was evaluated by assessing if comparable outcomes were observed for members of the fraction, and if these effects were observed at similar dose levels.

3 The OECD Existing Chemicals Database (https://hpvchemicals.oecd.org) was reviewed for relevant categories, and dossiers for the following categories were screened: diethylbenzenes (DEBs), C9 aromatic solvents, and C10–C13 aromatic solvents. In addition, the Oecd (1994) hazard characterization for 1,4-DEB was reviewed for relevant toxicity data.