# 1 INTRODUCTION

This Provisional Peer-Reviewed Toxicity Value (PPRTV) assessment supports a fraction-based approach to risk assessment for mixtures of petroleum hydrocarbons U.S. EPA (2022). In this approach, total petroleum hydrocarbon (TPH) fractions are defined based on expected transport in the environment and analytical methods used to quantify environmental contamination by TPH mixtures. TPH components were first classified into aromatics and aliphatics, and each of these two major fractions were further separated into low, medium, and high carbon range fractions. This PPRTV assessment describes the derivation of both noncancer and cancer toxicity values for the aromatic medium carbon range fraction of TPH. The toxicity values described herein are used in the assessment of Complex Mixtures of Petroleum Hydrocarbons that is intended to replace current approaches used at TPH-contaminated sites U.S. EPA (2022).

In general, fraction-based approaches involve: (1) dividing a complex mixture into groups based on similarities in their chemical structures or chemical properties; (2) measuring the concentrations of these groups (or the components within the group) in environmental media or estimating the rates of human exposure (e.g., mg/kg-day) to these groups; (3) selecting an approach to characterize a dose-response relationship for the group; (4) combining the dose-response approach and the exposure estimates for all members of the group to estimate health risks from the group; and (5) estimating risks or hazards posed by exposure to the complex mixture using the risk characterization information from the individual groups [adapted from Atsdr (2018)].

## 1.1 DEFINITION OF THE AROMATIC MEDIUM CARBON RANGE FRACTION

The aromatic medium carbon range fraction includes aromatic hydrocarbons with a carbon (C) range of C9–C10 (contains between 9 and 10 carbons, inclusive) and an equivalent carbon (EC) number^1^ index range of EC9–EC < 11^2^ that occur in, or co-occur with, petroleum contamination. It should be noted that the aromatic high carbon range fraction also includes C10 compounds, but unlike the aromatic high carbon range fraction, the aromatic medium carbon range fraction is restricted to those with EC9–EC < 11; the aromatic high carbon range fraction includes those compounds with an EC11–EC35. The EC index is equivalent to the retention time of the compound on a boiling-point gas chromatography (GC) column (nonpolar capillary column), normalized to the n-alkanes NJ DEP (2010). EC numbers are the physical characteristic that underpin analytical separation of petroleum components. EC numbers are useful because they are more closely related to environmental mobility than carbon number. For instance, two chemicals with similar carbon numbers but different structures (e.g., aliphatic vs. aromatic) could partition differently into environmental media and, ultimately, have different environmental fates. Grouping based on EC numbers provides a consistent basis for logically placing petroleum hydrocarbon compounds into fractions because EC measures correlate with physicochemical properties such as water solubility, vapor pressure, Henry’s law constant, and soil adsorption coefficient (log K_oc_).

Toxicological considerations also contributed to the definition of the aromatic medium carbon range fraction. Substituted benzenes (C9–C10; contained within the aromatic medium carbon fraction) were grouped separately from PAHs, naphthalenes, and 1,1-biphenyl (contained within the aromatic high carbon fraction), which generally exhibit greater carcinogenicity and noncancer toxicity. Example compounds in the aromatic medium carbon range fraction include isopropylbenzene (a C9 aromatic compound with an EC of 8.66) and n-butylbenzene (a C10 aromatic compound with an EC of 9.96). The selection of relevant compounds and mixtures is described in Section 2 and Appendix A.

## 1.2 OVERVIEW OF PHYSICOCHEMICAL PROPERTIES AND ENVIRONMENTAL FATE

The systematic chemical names, synonyms [following guidance in Nist (2020b)], CASRNs, chemical abbreviations, chemical structures, and molecular weights for chemicals in this document are listed in Table 1 and in Appendix B of U.S. EPA (2022). The physicochemical properties for chemicals of the aromatic medium carbon range fraction that have toxicity values compiled from the CompTox Chemicals Dashboard U.S. EPA (2021) are provided in Table 2. Section 2 details how fraction members with toxicity values were identified. As Table 2 shows, the eight chemicals with toxicity values include both C9 and C10 compounds. The eight chemicals selected to represent the components of the aromatic medium carbon range fraction are all liquids at room temperature with moderate water solubility and high vapor pressure. All fraction members contain an alkyl substituted aromatic ring; three of the members contain three methyl groups on an aromatic ring (CASRNs 108-67-8, 95-63-6, and 526-73-8), three have one branched alkyl group on an aromatic ring (CASRNs 98-82-8, 98-06-6, and 135-98-8), and two have one linear alkyl group on an aromatic ring (CASRNs 103-65-1 and 104-51-8). Members of this fraction are expected to have negligible to slow mobility in soil. Volatilization may occur from water and moist soil (based upon measured and estimated Henry’s law constant values) and from dry soil surfaces (based upon measured vapor pressure data); however, adsorption to soil is expected to attenuate volatilization of the fraction members from soil. Measured aerobic and anaerobic biodegradation data are available for the representative compounds. Aromatic hydrocarbons typically have slow biodegradation rates under aerobic conditions and slow to no biodegradation under anaerobic conditions. However, more rapid biodegradation has been reported for some of the members of this fraction. For example, in activated sludge from a predominantly domestic wastewater treatment plant, sec-butylbenzene and n-butylbenzene had 56–67 and 72–80% removal, respectively, in 5 days at 25°C at test substance concentrations of 100 mg/L NCBI (2022a, b). Members of the aromatic medium carbon range fraction do not contain hydrolysable functional groups; therefore, the rate of hydrolysis is expected to be negligible for all fraction members. In the atmosphere, the rate of photooxidation is expected to range from slow (tert-butylbenzene) to rapid for the vapor-phase forms of the fraction members. The fraction members do not contain chromophores that absorb at wavelengths >290 nm and are therefore not expected to be susceptible to direct photolysis by sunlight Nlm (2013, 2008a, b, c, 2005, 2004a, b, 2003).

Table 1 Synonyms and Abbreviations for Chemicals in This Document^a^

Chemical Name (common synonyms)^b^ | CASRN | Abbreviation | Structure | Molecular Weight (g/mol)
1,2,3-Trimethylbenzene; (benzene, 1,2,3-trimethyl-) | 526-73-8 | 1,2,3-TMB | 1,2,3-Trimethylbenzene Structure | 120.195
1,2,4-Trimethylbenzene; (benzene, 1,2,4-trimethyl-) | 95-63-6 | 1,2,4-TMB | 1,2,4-Trimethylbenzene Structure | 120.195
1,3,5-Trimethylbenzene; (benzene, 1,3,5-trimethyl-) | 108-67-8 | 1,3,5-TMB | 1,3,5-Trimethylbenzene Structur | 120.195
Isopropylbenzene; (cumene; [propan-2-yl]benzene; benzene, [1-methylethyl]-) | 98-82-8 | | Isopropylbenzene Structure | 120.195
HFAN; (light aromatic solvent naphtha [petroleum]; solvent naphtha, petroleum, light aromatic; super high flash naphtha; aromatic solvent; solvent, aromatic petroleum; solvent naphtha; light aromatic solvent naphtha; low boiling point naphtha–unspecified; solvent naphtha [petroleum], light aromatic) | 64742-95-6 | | Various | Various
n-Butylbenzene; (benzene, butyl-) | 104-51-8 | | n-Butylbenzene Structure | 134.222
n-Propylbenzene; (propylbenzene; benzene, propyl-) | 103-65-1 | | n-Propylbenzene Structure | 120.195
sec-Butylbenzene; ([butan-2-yl]benzene; benzene, [1-methylpropyl]-) | 135-98-8 | | sec-Butylbenzene Structure | 134.222
tert-Butylbenzene; (benzene, [1,1-dimethylethyl]-) | 98-06-6 | | tert-Butylbenzene Structure | 134.222

a Only chemicals with toxicity values are listed.

b Synonyms are listed according to National Institute of Standards and Technology Nist (2020b) and include valid synonyms from the U.S. EPA CompTox Chemicals Dashboard; https://comptox.epa.gov/dashboard; accessed 03-30-2020.

U.S. EPA = U.S. Environmental Protection Agency.

Table 2 Physicochemical Properties of Aromatic Medium Carbon Range Chemicals with Toxicity Values^a^

Chemical | Isopropylbenzene | n-Propyl-benzene | 1,3,5-TMB | 1,2,4-TMB | 1,2,3-TMB | tert-Butyl-benzene | sec-Butyl-benzene | n-Butyl-benzene
Structure | Shape, polygon Description automatically generated | A picture containing engineering drawing Description automatically generated | Diagram, schematic Description automatically generated | Diagram, schematic Description automatically generated | Diagram Description automatically generated | Diagram Description automatically generated | Diagram Description automatically generated | A picture containing diagram Description automatically generated
CASRN | 98-82-8 | 103-65-1 | 108-67-8 | 95-63-6 | 526-73-8 | 98-06-6 | 135-98-8 | 104-51-8
Molecular formula | C_9_H_12_ | C_9_H_12_ | C_9_H_12_ | C_9_H_12_ | C_9_H_12_ | C_10_H_14_ | C_10_H_14_ | C_10_H_14_
EC number^b^ | 8.66 | 8.94 | 9.15 | 9.36 | 9.65 | 9.36 | 9.57 | 9.96
Molecular weight (g/mol) | 120.195 | 120.195 | 120.195 | 120.195 | 120.195 | 134.222 | 134.222 | 134.222
Melting point (°C) | −96 | −99.6 | −44.9 | −46.0 | −25.4 | −58.3 | −73.6 | −88.0
Boiling point (°C) | 152 | 159 | 164 | 169 | 176 | 169 | 174 | 183
Vapor pressure (mm Hg at 25°C) | 4.50 | 3.42 | 2.48 | 2.10 | 1.69 | 2.20 | 1.75 | 1.06
Henry’s law constant (atm-m^3^/mole at 25°C) | 1.15 × 10^−2^ | 1.05 × 10^−2^ | 8.77 × 10^−3^ | 6.16 × 10^−3^ | 4.36 × 10^−3^ | 7.89 × 10^−3^ | 8.03 × 10^−3^ | 8.05 × 10^−3^
Water solubility (mol/L at 25°C) | 5.24 × 10^−4^ | 4.65 × 10^−4^ | 3.99 × 10^−4^ | 4.78 × 10^−4^ | 6.30 × 10^−4^ | 2.19 × 10^−4^ | 1.30 × 10^−4^ | 8.73 × 10^−5^
Log K_ow_ | 3.66 | 3.71 | 3.50 | 3.63 | 3.63 | 4.11 | 4.57 | 4.38
Log K_oa_ | 3.98 | 4.09 | 4.54^*^ | 4.54^*^ | 4.54^*^ | 4.46^*^ | 4.31^*^ | 4.60^*^
Log K_oc_ | 3.00^*^ | 2.87 | 2.82 | 3.05^*^ | 2.80 | 3.34^*^ | 3.76^*^ | 3.39

a Data are presented as experimental averages from the U.S. EPA CompTox Chemicals Dashboard unless otherwise stated; https://comptox.epa.gov/dashboard; updated 02-03-2021.

b EC number was developed by the TPHCWG and is proportional to the BP of a chemical. EC number is analogous to an n-paraffin retention time index and can be estimated using: EC = 4.12 + 0.02 (BP) + 6.5 × 10^−5^ (BP)^2^ NIST (2020a; Edwards et al. (1997; Gustafson et al. (1997b).

* Predicted value.

BP = boiling point; EC = equivalent carbon; K_oa_ = octanol-air partition coefficient; K_oc_ = soil adsorption coefficient; K_ow_ = octanol-water partition coefficient; TMB = trimethylbenzene; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group.

## 1.3 OVERVIEW OF MIXTURE ASSESSMENT METHODS

A number of different approaches have been developed and used to estimate risks and hazards posed by exposures to chemical mixtures encountered in the environment. Among the simplest of these approaches to implement is the indicator chemical approach Atsdr (2018). The indicator chemical approach estimates the risk or hazard of a mixture by evaluating the dose-response assessment developed for a component of the mixture to the exposure rate of the entire mixture. The indicator chemical approach is used when there are only measures of the concentrations of this fraction (i.e., no information is available on the concentrations of individual chemicals in this fraction) (see Section 1.3.1). The hazard index (HI) approach (the other approach that will be addressed in this PPRTV assessment) can be used when there are measured concentrations of specific chemical compounds. In the HI approach, the individual chemical intake rates (or concentrations in the air) are divided by the reference dose (RfD) (or reference concentration [RfC]) for the chemical to estimate a hazard quotient (HQ). The HQs are summed to estimate the HI (see Section 1.3.2). The indicator chemical approach has greater uncertainty than the HI approach (see Figure 1).

The U.S. Environmental Protection Agency’s (U.S. EPA) Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures U.S. EPA (2000, 1986) describes the following two broad categories of approaches for assessing human health risks and health hazards associated with environmental exposures to chemical mixtures: component methods and whole mixture methods. Component-based approaches, which involve analyzing the toxicity of a mixture’s individual components, have more uncertainty and are recommended when toxicity data on a complex mixture of concern, or on a sufficiently similar mixture (discussed below), are unavailable U.S. EPA (2000, 1986). In this PPRTV, a component approach, the HI approach, is described for assessing noncancer hazards posed by exposures to the aromatic medium carbon range fraction.

Chemical mixture assessments are conducted most appropriately with quantitative dose-response information resulting from comparable exposures to the mixture of concern. If the dose-response data are insufficient to develop a health reference value for the specific mixture of concern in the environment, the second option that the U.S. EPA’s Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures U.S. EPA (2000, 1986) recommended is a “sufficient similarity” approach that uses a health reference value from a characterized surrogate mixture to estimate the hazard or risk associated with exposures to the mixture of concern. This method requires chemistry and toxicity data on both the potential surrogate mixture and the mixture of concern (e.g., a key event that is related to the apical endpoint observed in an epidemiological study or whole animal study), and a health reference value (e.g., from an in vivo study) on the surrogate mixture. If the chemistry and toxicity data indicate that the mixtures are “sufficiently similar” to one another, then the health reference value for the surrogate mixture can be used as a proxy for the mixture of concern. No data were identified that were suitable to implement a whole mixture approach.

The choice of a chemical mixtures risk assessment method is driven by the available data. Starting with the method requiring the least information and then discussing the method requiring more information, the following subsections summarize the indicator chemical approach and the HI approach. Figure 1 summarizes the two approaches and the preference for using each approach.

Figure 1 Provisional Peer-Reviewed Toxicity Approaches for the Aromatic Medium Carbon Range TPH Fraction Noncancer Assessment

Two approaches are available to estimate the noncancer hazards associated with exposure to the aromatic medium range fraction. Approach selection should be driven by the available exposure data. Increased analytical characterization of fraction components allows for more refined health hazard estimates with less inherent uncertainty. Approach preference is inversely correlated with approach uncertainty.

HQ = hazard quotient; TMB = trimethylbenzene.

A picture containing icon Description automatically generated

### 1.3.1 Indicator Chemical Approach

When the chemical composition of a mixture or a mixture fraction is not known, or toxicity measures are not available for individual chemicals in a mixture, the toxicity of an individual chemical can be used as an indicator for the toxicity of a mixture or a mixture fraction Atsdr (2018). Atsdr (2018) describes an indicator chemical as “a chemical … selected to represent the toxicity of a mixture because it is characteristic of other components in the mixture and has adequate dose-response data.” Indicator chemical approaches are typically implemented to assess health risks in a health-protective manner; the chemical chosen as an indicator is among the best characterized toxicologically and likely among the most potent components of the mixture. The indicator chemical needs to have adequate dose-response data to indicate hazard potential or a dose-response relationship for noncancer outcomes, depending on the purpose of the assessment. The health risk value of the indicator chemical is integrated with exposure estimates for the mixture or mixture fraction to estimate health hazard associated with the fraction (i.e., calculate fraction-specific HI for a specific exposure pathway). This approach does not scale for potency of individual constituents; instead, it assumes that the toxicity of all measured members of the fraction can be adequately estimated, given the purpose of the risk assessment, by the indicator chemical.

### 1.3.2 Hazard Index Approach

The HI approach combines estimated population exposures with toxicity information to characterize the potential for adverse effects. The HI is not a risk estimate, in that it is not expressed as a probability, nor is it an estimate of a toxicity measure (e.g., percentage decrement in enzyme activity). Instead, the HI is an indicator of potential hazard. In the HI approach, a HQ is calculated as the ratio of human exposure (E) to a health hazard reference value (RfV) for each mixture component chemical (i) U.S. EPA (1986). These HQs are summed to yield the HI for the mixture. In health risk assessments, the U.S. EPA’s preferred RfVs are the RfD for the oral exposure route and the RfC for the inhalation exposure route.

H I = ∑_i = 1_^n^ H Q_i_ = ∑_i = 1_^n^ (E_i_)/(R f V_i_)

The HI is based on dose addition U.S. EPA (2000; Svendsgaard and Hertzberg (1994); the hazard is evaluated as the potency-weighted sum of the component exposures. The HI is dimensionless, so E and the RfV must be in the same units.

1 Based on an empirical relationship, the EC value can be estimated from a compound’s boiling point (BP; °C) using the following equation: EC = 4.12 + 0.02 (BP) + 6.5 × 10^−5^ (BP)^2^; see Gustafson et al. (1997a).

2 This range reflects EC values rounded to the nearest whole number. For instance, isopropylbenzene (EC = 8.66) is included in this fraction because its EC value rounds to 9.