# APPENDIX C REFERENCES

Atsdr. (2018). Framework for assessing health impacts of multiple chemicals and other stressors (update). Washington, DC: U.S. Department of Health and Human Services. https://www.atsdr.cdc.gov/interactionprofiles/ip-ga/ipga.pdf.
Cometto-Muniz, JE; Abraham, MH. (2009). Olfactory detectability of homologous n-alkylbenzenes as reflected by concentration-detection functions in humans. Neuroscience 161: 236–248. 10.1016/j.neuroscience.2009.03.029.19303922
Darmer, KI, Jr; Neeper-Bradley, TL; Cushman, JR; Morris, CR; Francis, BO. (1997). Developmental toxicity of cumene vapor in CD rats and New Zealand white rabbits. Int J Toxicol 16: 119–139. 10.1080/109158197227224.
Edwards, DA; Andriot, MD; Amoruso, MA; Tummey, AC; Bevan, CJ; Tveit, A; Hayes, LA; Youngren, SH; Nakles, DV. (1997). Total petroleum hydrocarbon criteria working group series: Volume 4: Development of fraction specific reference doses (RFDs) and reference concentrations (RFCs) for total petroleum hydrocarbons (TPH). Amherst, MA: Amherst Scientific Publishers.
Eggersdorfer, M. (2012). Terpenes. In Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co. https://onlinelibrary.wiley.com/doi/pdf/10.1002/14356007.a26_205.
Gagnaire, F; Becker, MN; De Ceaurriz, J. (1992a). Alteration of brainstem auditory evoked potentials in diethylbenzene and diacetylbenzene-treated rats. J Appl Toxicol 12: 343–350. 10.1002/jat.2550120510.1447480
Gagnaire, F; Becker, MN; Marignac, B; Bonnet, P; de Ceaurriz, J. (1992b). Diethylbenzene inhalation-induced electrophysiological deficits in peripheral nerves and changes in brainstem auditory evoked potentials in rats. J Appl Toxicol 12: 335–342. 10.1002/jat.2550120509.1332994
Gagnaire, F; Marignac, B; de Ceaurriz, J. (1990). Diethylbenzene-induced sensorimotor neuropathy in rats. J Appl Toxicol 10: 105–112.2362075
Gustafson, JB; Griffith Tell, J; Orem, D. (1997a). Total petroleum hydrocarbon criteria working group series: Volume 3: Selection of representative TPH fractions based on fate and transport considerations. In Total Petroleum Hydrocarbon Criteria Working Group Series. Amherst, MA: Amherst Scientific Publishers. https://netforum.avectra.com/eweb/shopping/shopping.aspx?pager=1&site=aehs&webcode=shopping&prd_key=146b7eaf-c92d-4e4b-af1f-092c5735a10b.
Gustafson, JB; Griffith Tell, J; Orem, D. (1997b). Total petroleum hydrocarbon criteria working group series: Volume 3: Selection of representative TPH fractions based on fate and transport considerations. Amherst, MA: Amherst Scientific Publishers. https://netforum.avectra.com/eweb/shopping/shopping.aspx?pager=1&site=aehs&webcode=shopping&prd_key=146b7eaf-c92d-4e4b-af1f-092c5735a10b.
Infante, PF; Bingham, E. (2012). Aromatic hydrocarbons-benzene and other alkylbenzenes (pp. 153–220). John Wiley & Sons, Inc. https://onlinelibrary.wiley.com/doi/10.1002/0471435139.tox051.pub2.
Magdalan, J; Zawadzki, M; Merwid-Lad, A. (2009). Fatal intoxication with hydrocarbons in deltamethrin preparation. Hum Exp Toxicol 28: 791–793. 10.1177/0960327109354939.19919971
MassDep. (2003). Updated petroleum hydrocarbon fraction toxicity values for the VPH/EPH/APH methodology. Boston, MA. https://www.mass.gov/files/documents/2016/08/ok/tphtox03.pdf.
McKee, RH; Adenuga, MD; Carrillo, JC. (2015). Characterization of the toxicological hazards of hydrocarbon solvents [Review]. Crit Rev Toxicol 45: 273–365. 10.3109/10408444.2015.1016216.25868376
NCBI (National Center for Biotechnology Information). (2022a). PubChem Compound summary: Butylbenzene. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/Butylbenzene (accessed
NCBI (National Center for Biotechnology Information). (2022b). PubChem Compound summary: Sec-butylbenzene. Available online at https://pubchem.ncbi.nlm.nih.gov/compound/Sec-butylbenzene (accessed
NIST (National Institute of Standards and Technology). (2020a). NIST 17 GC method/retention index library [Database]. Retrieved from https://chemdata.nist.gov/dokuwiki/doku.php?id=chemdata:ridatabase
Nist. (2020b). NIST special publication 922: Polycyclic aromatic hydrocarbon structure index. U.S. Department of Commerce Technology Administration. https://www.nist.gov/system/files/documents/2020/08/03/sp922_2020.pdf.
NJ DEP (New Jersey Department of Environmental Protection). (2010). Analysis of extractable petroleum hydrocarbon compounds (EPH) in aqueous and soil/sediment/sludge matrices (Revision 3 ed.). (NJDEP EPH 10/08). New Jersey Department of Environmental Protection Site Remediation Program Office of Data Quality. https://www.nj.gov/dep/srp/guidance/srra/eph_method.pdf.
NLM (National Library of Medicine). (2003). Hazardous substances data bank. N-propylbenzene. CASRN: 103-65-1. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5353.
NLM (National Library of Medicine). (2004a). Hazardous substances data bank. n-Butylbenzene. CASRN: 104-51-8. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/7211.
Nlm. (2004b). Hazardous substances data bank. Sec-Butylbenzene. CASRN: 135-98-8. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/7212.
NLM (National Library of Medicine). (2005). Hazardous substances data bank. T-butylbenzene. CASRN: 98-06-6. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5315.
Nlm. (2008a). Hazardous substances data bank. 1,2,3-trimethylbenzene. CASRN: 526-73-8. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/7551.
NLM (National Library of Medicine). (2008b). Hazardous substances data bank. 1,2,4-trimethylbenzene. CASRN: 95-63-6. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5293.
Nlm. (2008c). Hazardous substances data bank. 1,3,5-trimethylbenzene. CASRN: 108-67-8. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/92.
Nlm. (2013). Hazardous substances data bank. Isopropylbenzene. CASRN: 98-82-8. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/172.
Ntp. (2009). Toxicology and carcinogenesis studies of cumene (CAS NO. 98-82-8) in F344/N rats and B6C3F1 mice (inhalation studies) [NTP] (pp. 1–200). (NTP TR 542; NIH Publication No. 09-5885). Research Triangle Park, NC. http://ntp.niehs.nih.gov/results/pubs/longterm/reports/longterm/tr500580/listedreports/tr542/index.html.
Oecd. (1994). SIDS initial assessment profile. CAS No. 105-05-5. Chemical name: Benzene, 1,4-diethyl.
Oecd. (2007). SIDS initial assessment profile: CAS No. 25340-17-4. Chemical name: Diethylbenzene, mixed isomers (DEB mixed isomers). https://hpvchemicals.oecd.org/UI/handler.axd?id=2bb369a1-c6e1-4494-ac56-6ad188d4e5ec.
OECD (Organisation for Economic Co-operation and Development). (2012a). SIDS initial assessment profile. Chemical category: C10-C13 aromatic hydrocarbon solvents category. CAS number and chemical names. Solvent naphtha, (petroleum), heavy aromatic: 64742-94-5. Hydrocarbons, C10, aromatics, >1% naphthalene. Hydrocarbons, C10, aromatics, <1% naphthalene. Hydrocarbons, C10-C13, aromatics, >1% naphthalene. Hydrocarbons, C10-C13, aromatics, <1% naphthalene. C9-10 aromatics, predominantly C9-C10 alkylbenzenes and naphthalene. Aromatics hydrocarbons, C9 – 11: 70693-06-0. Napthalane, methyl (mixed) 1321-94-4. Hydrocarbons, C11, aromatics. https://hpvchemicals.oecd.org/ui/handler.axd?id=884A80E0-A657-48CD-8748-CD361A682D06.
Oecd. (2012b). SIDS initial assessment profile: Chemical category: C9 aromatic hydrocarbon solvents category. CAS numbers and chemical names: 95-63-6: Benzene, 1,2,4-trimethyl. 108-67-8: Benzene, 1,3,5-trimethyl. 25550-14-5: Benzene, ethylmethyl (ethyltoluene mixed isomers). 64742: Solvent naphtha, (petroleum), light aromatic.
Svendsgaard, DJ; Hertzberg, RC. (1994). Statistical methods for the toxicological evaluation of the additivity assumption as used in the Environmental Protection Agency chemical mixture risk assessment guidelines. In RSH Yang (Ed.), Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches (pp. 599–642). San Diego, CA: Academic Press.
Swiercz, R; Rydzyński, K; Jajte, J; Stetkiewicz, J; Majcherek, W. (2000). Studies on dermal, ocular and respiratory effects of 4-ethyltoluene in experimental animals. Int J Occup Med Environ Health 13: 307–315.11276844
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for the health risk assessment of chemical mixtures (pp. 1–38). (EPA/630/R-98/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=22567.
U.S. EPA (U.S. Environmental Protection Agency). (1991). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. (EPA625391019F. PB92143668). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB92143668.
U.S. EPA (U.S. Environmental Protection Agency). (1997). Toxicological review of cumene (CAS no. 98-82-8) in support of summary information on the Integrated Risk Information System [EPA Report]. (EPA63SR98001). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0306tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2000). Supplementary guidance for conducting health risk assessment of chemical mixtures (pp. 1–209). (EPA/630/R00/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=20533.
U.S. EPA (U.S. Environmental Protection Agency). (2007). Provisional peer-reviewed toxicity values for 1,2,4-trimethylbenzene (CASRN 95-63-6) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Trimethylbenzene124.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2009a). Provisional peer-reviewed toxicity values for anthracene (CASRN 120-12-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Anthracene.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2009b). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/ComplexMixturesofAliphaticandAromaticHydrocarbons.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2009c). Provisional peer-reviewed toxicity values for high flash aromatic naphtha (CASRNs 64724-95-6 and 88845-25-4) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/NaphthaHighFlashAromaticHFAN.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2009d). Provisional peer-reviewed toxicity values for n-propylbenzene (CASRN 103-65-1) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Propylbenzenen.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2010). Provisional peer-reviewed toxicity values for n-butylbenzene (CASRN 104-51-8) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Butylbenzenen.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Provisional peer-reviewed toxicity values for p-isopropyltoluene (CASRN 99-87-6) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Isopropyltoluenep.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Provisional peer-reviewed toxicity values for sec-butylbenzene (CASRN 135-98-8) [EPA Report]. (EPA/690/R-12/004F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Butylbenzenesec.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Provisional peer-reviewed toxicity values for tert-butylbenzene (CASRN 98-06-6) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Butylbenzenetert.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Toxicological review of trimethylbenzenes (CASRNs 25551-13-7, 95-63-6, 526-73-8, and 108-67-8). (EPA/635/R-16/161Fa). U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1037tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Toxicological review of trimethylbenzenes [CASRNs 25551-13-7, 95-63-6, 526-73-8, and 108-67-8] supplemental information. (635R16161Fb). Washington, DC.
U.S. EPA (U.S. Environmental Protection Agency). (2021). CompTox chemicals dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2022). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH.
Wang, NCY; Rice, GE; Teuschler, LK; Colman, J; Yang, RSH. (2012). An in silico approach for evaluating a fraction-based, risk assessment method for total petroleum hydrocarbon mixtures. J Toxicol 2012: 410143. 10.1155/2012/410143.22496687