# APPENDIX B POTENTIALLY RELEVANT NONCANCER EVIDENCE

## DEVELOPMENT OF EXPOSURE-RESPONSE ARRAYS

As described in the main document, dose-response data were presented in exposure-response arrays by health outcome and exposure route. In order to assess consistency in effects and potency across the components of the fraction, experimental data from compound specific Integrated Risk Information System (IRIS) and Provisional Peer Reviewed Toxicity Value (PPRTV) documents and primary data sources (identified from literature searches) were used to create exposure-response arrays. Exposure-response arrays present dose-response data by health outcome and exposure route. From left to right, compounds exhibiting an effect are shown before those not exhibiting an effect, to enable identification of patterns. Within the group exhibiting an effect, compounds are ordered from lowest lowest-observed-adverse-effect level (LOAEL) to highest. For compounds that do not exhibit an effect, no-observed-adverse-effect levels (NOAELs) in the arrays are ordered by equivalent carbon (EC) number index (low to high from left to right), with mixtures shown last. Both administered doses and exposure concentrations reported in the arrays and in text reflect time-weighted average (TWA) exposures, to facilitate comparisons across studies and compounds. Consistency across the fraction was evaluated by assessing if comparable outcomes were observed for members of the fraction, and if these effects were observed at similar dose levels. Unless otherwise specified, the term “significant,” used throughout this appendix, refers to statistical significance at a p-value < 0.05.

## NEUROLOGICAL EFFECTS

A nervous system endpoint (decreased pain sensitivity) is the critical effect for the subchronic and chronic reference concentration (RfC) values for trimethylbenzene (TMB) isomers, with data for 1,2,4-TMB being the driver for these values U.S. EPA (2016b). Oral toxicity values (i.e., subchronic and chronic reference doses [RfDs]) for TMBs were derived based on route-to-route extrapolation (using a modified physiologically based pharmacokinetic [PBPK] model) from the inhalation values. Neurological effects (including effects on motor coordination, cognitive function, vision, and the inner ear) have been reported in humans occupationally exposed to solvents including TMBs; however, the effects cannot be attributed to specific compounds. Neurotoxicity data in humans are limited to TMBs, and there are no human data for other members of the aromatic medium carbon range fraction. Animal studies examining neurological endpoints are available for most of the compounds or mixtures with toxicity data; however, the studies varied widely with respect to the nature of the neurological endpoints evaluated.

### Human Studies

U.S. EPA (2016b) reviewed the evidence for neurotoxicity in humans exposed to TMBs alone or in complex mixtures. Much of the epidemiological evidence is from occupational exposures to complex mixtures including TMBs, and the relative contribution of TMBs compared with other constituents is not known. Associations between exposure of dockyard and shipyard painters to solvent mixtures possibly containing TMBs and impaired performance in a battery of neurological tests, including short-term memory (symbol digit substitution), motor speed/coordination (finger tapping), and peripheral nerve function tests, were reported in several studies U.S. EPA (2016b). Other neuropsychological symptoms (mood changes, equilibrium complaints, and sleep disturbances) were also observed among shipyard painters. Similarly, paint factory workers exposed to multiple unspecified solvents had detrimental neuropsychological effects (memory problems, dizziness, hand tremble), and construction workers exposed to solvent mixtures had impaired performance in memory tasks U.S. EPA (2016b).

Other researchers reported damage or dysfunction of the inner ear and increased incidence of vertigo following workplace exposure (in paint and varnish factories and histology laboratories) to TMBs and other organic solvents U.S. EPA (2016b). Suggestive evidence of visual impairment (altered color vision and contrast) among furniture factory workers was reported following exposure to complex solvent mixtures. Increased latencies for visual evoked potentials (VEPs) were found in gasoline-exposed workers. There is suggestive evidence from multiple studies of human exposure to solvent mixtures containing TMB isomers that exposure results in toxicological effects on neuromuscular function and balance in humans, including increased reaction time, increased hand tremble, decreased hand-eye coordination, and vertigo U.S. EPA (2016b). Finally, symptoms associated with central nervous system (CNS) depression (e.g., lightheadedness, fatigue) have been reported in workers occupationally exposed to solvent mixtures containing TMBs U.S. EPA (2016b).

A significant, positive association between exposure and neurological symptoms (such as abnormal fatigue) was reported among asphalt workers exposed to 1,2,4-TMB; however, the association was not evident among asphalt workers with exposure to lower levels of 1,2,3-TMB or 1,3,5-TMB U.S. EPA (2016b). Paint shop workers exposed to 49–295 mg/m^3^ of a solvent mixture containing 50% 1,2,4-TMB, 30% 1,3,5-TMB, and unspecified amounts of 1,2,3-TMB (listed as possibly present) exhibited a variety of neurological effects including nervousness, tension, headaches, vertigo, and anxiety U.S. EPA (2016b).

Studies of adult volunteers who were acutely exposed to mixtures containing 1,2,4-TMB reported significant and consistent increases in reaction time, although it is unclear whether 1,2,4-TMB or other constituents in the mixtures were responsible for the observed effects. Neurobehavioral impairment was either weakly or inconsistently associated with exposure in a volunteer study in which participants were exposed to aromatic or dearomatized white spirit (white spirit contains a mixture of 1,2,4- and 1,3,5-TMB) for 4 hours U.S. EPA (2016b).

The few available controlled human exposure studies of TMBs alone have not shown neurological effects U.S. EPA (2016b). No neurological abnormalities were reported in routine clinical examinations in two studies investigating the toxicokinetics of TMBs following controlled human exposures to 5–150 mg/m^3^ of 1,2,3-, 1,2,4-, or 1,3,5-TMB; however, neither results data nor details regarding the specific neurological tests performed were provided. In another controlled toxicokinetics study, no overt CNS depression (measured as heart rate and respiration) or increase in subjective CNS symptoms (headache, fatigue, nausea, dizziness, intoxication) was observed in volunteers exposed to concentrations ≤123 mg/m^3^ of TMB isomers U.S. EPA (2016b).

### Animal Studies

Animals exposed orally to diethylbenzenes (DEBs) (individual isomers, as well as a mixture containing 7% 1,2-DEB, 58% 1,3-DEB, and 35% 1,4-DEB) have been evaluated for peripheral nervous system and CNS effects. No oral data on the neurotoxicity of the other members of the aromatic medium carbon range fraction were located. Figure B-1 is an exposure-response array containing studies for which neurotoxicity effects levels could be reliably determined. Reductions in sensory conduction velocity (SCV), motor nerve conduction velocity (MCV), and amplitude of the sensory action potential (SAP) (of the tail nerve) occurred after exposure to 57 mg/kg-day 1,2-DEB and ≥357 mg/kg-day of the DEB mixture (lowest doses tested) Gagnaire et al. (1990). The same parameters were unaffected in rats treated with 1,3- or 1,4-DEB at 357 mg/kg-day. In a follow-up study, rats administered 1,2-DEB at ≥43 mg/kg-day also showed significantly increased latencies with respect to parameters of brainstem auditory evoked potentials (BAEPs) Gagnaire et al. (1992a).

Neurological effects evaluated after inhalation exposure to aromatic medium carbon range compounds include clinical signs of neurotoxicity, neurobehavioral changes, peripheral nervous system and CNS function, and brain histopathology. Figure B-2 is an exposure-response array containing studies for which neurotoxicity effect levels could be reliably determined. Data were available for six members of the fraction. Clinical signs of neurotoxicity (side-to-side movement and head tilt) were observed in rats treated with isopropylbenzene at ≥92 mg/m^3^ for 4 weeks Monsanto Company, 1986 as cited in U.S. EPA (1997). Significant neurobehavioral changes (impairments in active and passive avoidance, increased motor activity, and/or reduced pain sensitivity) were observed in rats treated with 1,2,4-, 1,3,5-, or 1,2,3-TMB at ≥88 mg/m^3^ Wiaderna et al., 2002, Gralewicz and Wiaderna, 2001, Wiaderna et al., 1998, Gralewicz et al., 1997a, and Korsak and Rydzynski, 1996, Lutz, 2010, all as cited in U.S. EPA (2016b). Decreased pain sensitivity in rats treated with 1,2,4-TMB at ≥88 mg/m^3^ serves as the basis for oral and inhalation subchronic and chronic RfDs and RfCs for all three TMB isomers Korsak and Rydzynski, 1996 as cited in U.S. EPA (2016b). Pain sensitivity was not significantly affected in rats exposed to HFAN at up to 1,157 mg/m^3^ for 90 days Douglas et al., 1993 as cited in U.S. EPA (2009c). There was no effect on nervous system histology in this study or on brain weight or histology in rats or mice following exposure to isopropylbenzene for 14 or 105 weeks at concentrations up to 907 mg/m^3^ Ntp (2009). Male rats exposed to a DEB mixture for 18 weeks showed decreased SCV, MCV, and amplitude of SAP (≥486 mg/m^3^) and increased latency of BAEP parameters (at ≥633 mg/m^3^) Gagnaire et al. (1992b). In a developmental study, no neurobehavioral effects were reported in rats exposed to HFAN at up to 500 mg/m^3^ on gestation days (GDs) 7–15; however, it is not clear if only pups or pups and dams were evaluated for effects Lehotsky, 1989 as cited in U.S. EPA (2009c).

Figure B-1 Neurological Effects in Animals after Oral Exposure to Aromatics Medium Carbon Range Compounds

Table Description automatically generated

Figure B-2 Neurological Effects in Animals after Inhalation Exposure to Aromatic Medium Carbon Range Compounds

A picture containing chart Description automatically generated

### Summary of Potentially Relevant Evidence

Available data indicate that neurological effects are associated with oral or inhalation exposure to some fraction members. In oral and inhalation toxicity studies using individual DEB isomers or a mixture of DEB isomers, effects on peripheral nervous system and/or CNS (SCV, MCV, amplitude of SAP, and BAEPs) were consistently observed for 1,2-DEB and the DEB mixture (but not 1,3-DEB or 1,4-DEB). Studies in animals show that exposure to TMBs via inhalation induces neurobehavioral effects (specifically, decreased pain sensitivity and increased motor activity and passive and active avoidance); data from human studies are available but are insufficient to establish causal relationships (owing to coexposures with other compounds). Limited data are available for the other members of the fraction. CNS effects (consisting of clinical signs of neurotoxicity) were observed in at least one other inhalation study (in rats exposed to isopropylbenzene). However, additional studies using this compound were not dedicated to neurotoxicity studies; only brain histopathology was evaluated (no effects were observed in subchronic and chronic studies in rats and mice). The most sensitive chemical- or mixture-specific LOAELs for neurological endpoints ranged between 43 and 357 mg/kg-day in subchronic oral toxicity studies in rats (see Figure B-1) and between 88 and 633 mg/m^3^ in subchronic inhalation toxicity studies in rats (see Figure B-2).

Taken together, the available data indicate that some members of the aromatic medium carbon range fraction can induce neurological effects. However, there are a number of compounds comprising the aromatic medium carbon range fraction that have not been evaluated for sensitive measures of neurological function.

## HEPATIC EFFECTS

A hepatic effect (hepatocellular hypertrophy) is the critical effect for the subchronic and chronic provisional reference doses (p-RfDs) for n-butylbenzene U.S. EPA (2010). In addition, effects on liver histopathology serve as a cocritical effects (with effects on kidney histopathology) for the screening-level subchronic and chronic p-RfDs for n-propylbenzene [based on the use of ethylbenzene (CASRN 100-41-4) as an analogue chemical U.S. EPA (2009a). No human data pertaining to the hepatotoxicity of aromatic medium carbon range fraction members were identified. As shown in Table 5, oral and/or inhalation data on hepatic effects in animals were located for seven members of the fraction. In general, the hepatic endpoints evaluated in the studies were clinical chemistry parameters, liver weight, and histology.

### Human Studies

No human studies were available to address the potential for hepatic toxicity of the TMB isomers or other members of the aromatic medium carbon range fraction by any route of exposure.

### Animal Studies

Animals orally administered four materials (three individual compounds and HFAN) in the aromatic medium carbon range have been evaluated for hepatotoxicity. Figure B-3 is an exposure-response array containing studies for which hepatic effects levels could be reliably determined. Increased absolute and/or liver weight was observed in rats treated with 1,3,5-TMB at 428 mg/kg-day for 90 days Adenuga et al., 2014 as cited in U.S. EPA (2016b), 1,4-DEB at 750 mg/kg-day for 6 weeks MHW, 1993b as cited in Oecd (1994), n-butylbenzene at 300 mg/kg-day for two generations Izumi et al., 2005 as cited in U.S. EPA (2010), and HFAN at ≥357 mg/kg-day for 13 weeks Biodynamics, 1990a and Mobil Oil Company, 1994 as cited in U.S. EPA (2009c). Relative liver weight was likewise increased in HFAN-treated dogs at 500 mg/kg-day; however, this effect may have been influenced by decreased terminal body weights (20% lower than controls) Biodynamics, 1990b as cited in U.S. EPA (2009c). With the exception of rats treated with 1,3,5-TMB, rats that exhibited increased liver weights also showed increased incidences of hepatocellular hypertrophy. A significantly increased incidence of hepatocellular hypertrophy (in F_0_ and F_1_ parental males) was the basis for subchronic and chronic RfDs for n-butylbenzene Izumi et al., 2005 as cited in U.S. EPA (2010). In addition, liver and kidney toxicity were designated as cocritical effects for screening-level subchronic and chronic RfDs for n-propylbenzene, based on analogy to ethylbenzene U.S. EPA (2009d).

Data evaluating hepatotoxicity via inhalation exposure were available for four members of the aromatic medium carbon range fraction. Figure B-4 is an exposure-response array containing studies for which hepatic effects levels could be reliably determined. Relative liver weight was biologically and statistically significantly increased at concentrations of ≥227 mg/m^3^ in rats and ≥454 mg/m^3^ in mice treated with isopropylbenzene for 14 weeks [NTP (2009); Cushman et al., 1995 as cited in U.S. EPA (1997) and at 2,823 mg/m^3^ in rabbits treated with isopropylbenzene on GDs 6–18 Darmer et al. (1997). Increased organ weight was accompanied by histopathological evidence of liver damage (e.g., eosinophilic foci and necrosis) after 105 weeks in mice Ntp (2009), but not rats Ntp (2009). No significant, treatment-related effects on liver weights and/or histopathology were observed in rats exposed to 1,2,4- or 1,2,3-TMB at concentrations up to 220 mg/m^3^ for 3 months Korsak et al. 2000a, b as cited in U.S. EPA (2016b), in rats exposed to HFAN at up to 327 mg/m^3^ for 3 months Clark et al., 1985 as cited in U.S. EPA (2009c), or in rabbits exposed to HFAN at up to 1,000 mg/m^3^ Clark et al., 1989 and Ungvary and Tartal, 1985 as cited in U.S. EPA (2009c).

Figure B-3 Hepatic Effects in Animals after Oral Exposure to Aromatic Medium Carbon Range Compounds

Figure B-4 Hepatic Effects in Animals after Inhalation Exposure to Aromatic Medium Carbon Range Compounds

Table Description automatically generated

### Summary of Potentially Relevant Evidence

Oral studies examining liver effects were limited to three compounds and one mixture (HFAN) in studies of 6 weeks to about 3 months in duration. All oral studies showed increases in liver weight; this effect was typically accompanied by changes in liver histopathology (namely, hepatocellular hypertrophy). Hepatic effects, predominantly consisting of increased relative weights, were also seen in inhalation studies in laboratory animals exposed to members of the aromatic medium carbon range fraction. Histological changes observed in the livers of animals exposed to members of the fraction included hepatocellular hypertrophy in multiple subchronic oral toxicity studies and eosinophilic foci in singular chronic inhalation toxicity studies (with several studies reporting no histological effects). Lowest LOAELs for hepatic endpoints ranged from 300 to 750 mg/kg-day in oral studies in rats (see Figure B-3; a LOAEL of 500 mg/kg-day was also identified in dogs), and from 227 to 454 mg/m^3^ in subchronic inhalation studies in rats and mice (see Figure B-4; excluding a LOAEL of 2,823 mg/m^3^ for increased liver weight in a developmental toxicity study in rabbits). In aggregate, the data suggest that many aromatic medium carbon range fraction compounds and mixtures can promote increases in rodent liver weight, sometimes accompanied by histological changes.

## RENAL EFFECTS

A renal endpoint (increased kidney weights in female F344 rats) is the critical effect for the chronic RfD and the cocritical effect (with increased adrenal weights) for the chronic RfC for isopropylbenzene U.S. EPA (1997). In addition, increased kidney weight serves as the critical effects for the screening-level subchronic and chronic p-RfDs for tert- and sec-butylbenzene U.S. EPA (2012a, b); these toxicity values are based on the use of isopropylbenzene as an analogue chemical. Effects on kidney histopathology were also identified as the critical effect in the study used to derive screening-level subchronic and chronic p-RfDs for n-propylbenzene U.S. EPA (2009d), based on the use of ethylbenzene as an analogue chemical. No human data pertaining to the renal toxicity of aromatic medium carbon range fraction members were identified. As shown in Table 5, data on renal effects in animals were located for seven members of the fraction. In general, the renal endpoints evaluated in the studies were kidney weight and histology; many also measured clinical chemistry parameters.

### Human Studies

No human studies were available to address the potential renal effects of the TMB isomers or other members of the aromatic medium carbon range fraction by any route of exposure.

### Animal Studies

Reliable data evaluating renal toxicity in animals after oral exposure to aromatic medium carbon range compounds were available for five members of the fraction. Figure B-5 is an exposure-response array containing studies for which renal effects levels could be reliably determined. These studies identified increased relative kidney weight as the most sensitive renal effect. Increased organ weight was observed in rats treated at ≥331 mg/kg-day with isopropylbenzene over 192 days (females only evaluated) Wolf, 1956 as cited in U.S. EPA (1997), 428 mg/kg-day with 1,3,5-TMB for 90 days Adenuga et al., 2014 as cited in U.S. EPA (2016b), 150 mg/kg-day with 1,4-DEB for about 6 weeks MHW, 1993b as cited in Oecd (1994), 300 mg/kg-day with n-butylbenzene for two generations (both generations) Izumi et al., 2005 as cited in U.S. EPA (2010), and ≥357 mg/kg-day with HFAN for about 13 weeks Biodynamics, 1990a and Mobil Oil Company, 1994 as cited in U.S. EPA (2009c). Kidney weight was likewise increased in HFAN-treated dogs at 500 mg/kg-day; however, this effect may have been influenced by decreased terminal body weights (20% lower than controls) Biodynamics, 1990b as cited in U.S. EPA (2009c). Increased serum blood urea nitrogen (BUN) was observed at the same dose as increased kidney weights in rats treated with 1,4-DEB MHW, 1993b as cited in Oecd (1994). Although changes in kidney histopathology were noted in at least one study of HFAN Mobil Oil Company, 1994 as cited in U.S. EPA (2009c), effects were seen in males only and the “male kidney sections had changes that may be consistent with nephropathy typical of male rats (dose-related hyaline droplet deposition, and nondose-related cortical tubular degeneration, consisting primarily of epithelial swelling)” U.S. EPA (2009c). These toxicities were consistent with rat-specific nephropathy, and U.S. EPA (1991) reported that these pathologies may not be considered relevant to humans. As such, the results of this are not presented in Figure B-5.

Renal effects seen after inhalation exposure to aromatic medium carbon range compounds are almost strictly limited to significantly increased relative kidney weight. Figure B-6 is an exposure-response array containing studies for which renal effects levels could be reliably determined. Organ weight was increased in rats exposed to isopropylbenzene at ≥454 mg/m^3^ for 14 weeks Ntp (2009), 1,055 mg/m^3^ for 13 weeks Cushman et al., 1995 as cited in U.S. EPA (1997), and 526 mg/m^3^ for 4 weeks Monsanto Company, 1986 as cited in U.S. EPA (1997); kidney weights were unaffected in mice treated at up to 907 mg/m^3^ for 14 or 105 weeks Ntp (2009). Although histopathological effects (e.g., granular casts, mineralization of renal papilla) were noted in isopropylbenzene-exposed rats, effects were seen in males only and were considered in the assessment to be consistent with rat-specific nephropathy (i.e., their relevance to humans is considered questionable) U.S. EPA (1997). In rats exposed to 1,2,4- or 1,2,3-TMB at up to 220 mg/m^3^ for 3 months, there was no evidence of renal toxicity based on kidney weights or histopathology Korsak et al. 2000a, b as cited in U.S. EPA (2016b). Similarly, rats exposed to HFAN at up to 327 mg/m^3^ for 12 months showed no consistent signs of kidney damage based on evaluations of clinical chemistry parameters and kidney histopathology Clark et al., 1989 as cited in U.S. EPA (2009c).

Figure B-5 Renal Effects in Animals after Oral Exposure to Aromatic Medium Carbon Range

Table Description automatically generated

Figure B-6 Renal Effects in Animals after Inhalation Exposure to Aromatic Medium Carbon Range Compounds

A picture containing text, screenshot, document Description automatically generated

### Summary of Potentially Relevant Evidence

Oral studies examining kidney effects were limited to four compounds and one mixture (HFAN) in studies of 4–27 weeks in duration. All studies showed increases in kidney weight; one study also reported a change in serum chemistry consistent with kidney damage (i.e., increased BUN). Changes in kidney histology were reported only in male rats for the four compounds and one mixture; these effects were consistent with rat-specific nephropathy. Kidney effects (increased relative kidney weights) were also seen in inhalation studies of animals exposed to one member of the aromatic medium carbon range fraction (isopropylbenzene). The lowest LOAELs (by compound or mixture) for increased kidney weights ranged from 150 to 500 mg/kg-day in oral studies in rats and dogs (see Figure B-5). For inhalation exposure, the lowest LOAEL was 454 mg/m^3^ for subchronic exposure to isopropylbenzene in rats (see Figure B-6). Inhalation studies of other compounds comprising the medium carbon fraction (including TMB isomers) did not indicate significant, treatment-related changes in kidney weights or histology. Taken together, the data indicate that several members of the aromatic medium carbon range fraction compounds and mixtures can produce increases in rodent kidney weight, sometimes accompanied by serum chemistry and histological changes.

## BODY-WEIGHT EFFECTS

Decreased maternal body weight on GD 15 is the critical effect in the study used to derive the subchronic and chronic provisional reference concentrations (p-RfCs) for HFAN U.S. EPA (2009c). No human studies examining body-weight effects of aromatic medium carbon range compounds were identified in the sources reviewed. As Table 5 shows, animal studies (oral or inhalation) that examined body weight as an endpoint are available for nearly all of the compounds and mixtures with toxicity data. Exceptions are n-propylbenzene and tert- and sec-butylbenzene. In this section, body-weight changes of at least 10% relative to controls in adult animals are considered LOAELs, and smaller changes are not. For studies that reported body-weight gain but did not report absolute body weights, and for studies of maternal weight gain during gestation, statistically significant changes from control are described.

### Human Studies

No human studies were available to address the potential for impacts on body weight of the TMB isomers or other members of the aromatic medium carbon range fraction by any route of exposure.

### Animal Studies

Figure B-7 shows the effects of orally-administered aromatic medium carbon range compounds and mixtures on body weight; data are available for seven materials. In studies of 1,3,5-TMB, 1,3-DEB, and n-butylbenzene, no treatment-related effects on body weight or body-weight gain were observed Adenuga et al., 2014 as cited in U.S. EPA (2016b; Izumi, 2005 as cited in U.S. EPA (2010; Gagnaire et al. (1990). However, decreased body weight/body-weight gain was seen after exposure to rats to 1,4-DEB at 750 mg/kg-day for 6 weeks MHW, 1993b as cited in Oecd (1994), 1,2-DEB at ≥43 mg/kg-day for 8 weeks Gagnaire et al. (1992a; Gagnaire et al. (1990), HFAN at ≥625 mg/kg-day on GDs 6–15 Biodynamics, 1990c as cited in U.S. EPA (2009c), and a mixture of DEB isomers at ≥357 mg/kg-day for 10 weeks Gagnaire et al. (1990). Dogs administered HFAN at 500 mg/kg-day (highest dose tested) for up to 90 days showed a 20% reduction in terminal body weights [albeit not statistically significant Biodynamics, 1990c as cited in U.S. EPA (2009c)].

Body-weight effects evaluated in subchronic and chronic inhalation toxicity studies are shown in Figure B-8; effects evaluated in developmental inhalation toxicity studies are shown in Figure B-9. Data via the inhalation route were available for six members of the aromatic medium carbon range fraction and a mixture of members of this fraction. As shown in Figure B-8, significant effects in subchronic or chronic studies are limited to rats exposed to mixtures comprising the aromatic medium range carbon fraction. HFAN-treated rats showed decreased body weights after treatment at 1,157 mg/m^3^ for 90 days Douglas et al., 1993 as cited in U.S. EPA (2009c). In addition, body-weight gain was significantly reduced in rats exposed to mixed DEB isomers at ≥486 mg/m^3^ for 18 weeks Gagnaire et al. (1992b). In contrast, no significant effects on body weight were observed following exposure of rats and mice to isopropylbenzene at up to 907 mg/m^3^ for 14 or 105 weeks Ntp (2009) or in rats exposed to isopropylbenzene at up to 1,055 mg/m^3^ for 13 weeks Cushman et al., 1995 as cited in U.S. EPA (1997). In addition, rats exposed to 1-methyl-4-ethylbenzene at up to 417 mg/m^3^ for 4 weeks Swiercz et al. (2000), or any of the three individual TMB isomers at up to 220 mg/m^3^ for 3 months showed no significant, treatment-related effects on body weight or body-weight gain Wiaderna et al., 2002, Korsak et al., 2000a, b, Gralewicz and Wiaderna, 2000, Wiaderna et al., 1998, Gralewicz et al., 1997a, and Korsak and Rydzynski, 1996, 1997, all as cited in U.S. EPA (2016b).

Significant effects on body weight/body-weight gain were observed in dams exposed to members of the aromatic medium carbon range fraction during the gestational period (see Figure B-9). Rats and rabbits exposed to high concentrations of isopropylbenzene during gestation (at ≥1,488 and 2,823 mg/m^3^, respectively) showed significantly reduced body-weight gains Darmer et al. (1997). After gestational exposure to 1,3,5-TMB (at ≥369 mg/m^3^) or 1,2,4-TMB (at ≥738 mg/m^3^), body-weight gain was likewise significantly decreased Saillenfait et al., 2014 as cited in U.S. EPA (2016b). Rabbits exposed to HFAN at up to 1,000 mg/m^3^ on GDs 7–20 showed no significant, treatment-related effects on body weight Ungvary and Tatrai, 1985 as cited in U.S. EPA (2009c), but mice exposed during gestation were affected at concentrations as low as 125 mg/m^3^ McKee et al., 1990 as cited in U.S. EPA (2009c).

Figure B-7 Body-Weight Effects in Animals after Oral Exposure to Aromatic Medium Carbon Range Fraction

Table Description automatically generated

Figure B-8 Body-Weight Effects in Animals after Subchronic and Chronic Inhalation Exposure to Aromatic Medium Carbon Range Compounds

Figure B-9 Body-Weight Effects in Animals after Gestational Inhalation Exposure to Aromatic Medium Carbon Range Compounds

Table Description automatically generated

### Summary of Potentially Relevant Evidence

Compounds and mixtures in the aromatic medium carbon range fraction have been shown to reduce body weights of rats, mice, rabbits, and dogs after oral and inhalation exposure. Members that induced body-weight changes in oral studies in rats included HFAN and DEBs (both individual isomers and mixed isomers); LOAELs for these effects ranged from 43 mg/kg-day (for 1,2-DEB) to 893 mg/kg-day (for HFAN) (see Figure B-7). In subchronic inhalation toxicity studies, rats exposed to HFAN and DEB mixtures (at 1,157 and ≥486 mg/m^3^, respectively) showed reductions in body weight/body-weight gain, whereas rats and mice exposed to individual compounds from the fraction (in the case of many compounds, at lower concentrations and/or for shorter time periods) did not (see Figure B-8). In general, rats, mice, and rabbits exposed to aromatic medium carbon range fraction compounds or mixtures during gestation showed treatment-related body-weight deficits; LOAELs for this effect were 125 mg/m^3^ for mice exposed to HFAN, between 369 and 1,488 mg/m^3^ for rats exposed to 1,3,5-TMB, 1,2,4-TMB, or isopropylbenzene, and 2,823 mg/m^3^ in rabbits exposed to isopropylbenzene (see Figure B-9). Taken together, the inhalation and oral animal data indicate that compounds in the aromatic medium carbon range fraction can be expected to induce body-weight reductions at sufficiently high doses (generally ≥500 mg/kg-day or duration-adjusted concentrations ≥300 mg/m^3^ for most compounds or mixtures).

## HEMATOLOGICAL EFFECTS

A hematological endpoint (anemia in dogs, with males being affected more than females) is the critical effect for the screening-level subchronic and chronic p-RfDs for HFAN U.S. EPA (2009c). Hematological effects (including anemia and effects on blood clotting) have been reported for humans occupationally exposed to solvent mixtures including TMBs; hematotoxicity cannot be attributed to specific isomers. Hematological data in humans are limited to TMBs; there are animal data (inhalation or oral) for six members of the aromatic medium carbon range fraction.

### Human Studies

Hematological effects have been reported in workers exposed by inhalation to mixtures containing TMB isomers. Workers exposed to paint solvent containing 50% 1,2,4-TMB, 30% 1,3,5-TMB, and unspecified amounts of 1,2,3-TMB (listed as possibly present) exhibited alterations in blood clotting and anemia at 295 mg/m^3^ U.S. EPA (2016b). Because occupational exposure studies involve solvent mixtures, hematological and clinical chemistry effects cannot be attributed to TMB isomers and may be due to other agents in the mixture. For example, the hematological effects may be attributed to trace amounts of benzene present in the solvent mixture U.S. EPA (2016b).

### Animal Studies

Reliable data regarding the hematotoxicity of aromatic medium carbon range compounds following oral exposure are limited to three members of the fraction. Figure B-10 is an exposure-response array containing studies for which hematological effects levels could be reliably determined. Increased monocytes were observed in rats treated with 1,3,5-TMB at ≥143 mg/kg-day for 90 days Adenuga et al., 2014 as cited in U.S. EPA (2016b), but no significant effects were reported after treatment with 1,4-DEB at up to 750 mg/kg-day for 6 weeks MHW, 1993b as cited in Oecd (1994). Although one 13-week study reported no significant, treatment-related effects on hematological parameters in rats treated with HFAN at up to 893 mg/kg-day Mobil Oil Company, 1994 as cited in U.S. EPA (2009c), two other studies of similar duration identified effects consistent with anemia (i.e., reductions in red blood cells [RBCs], hematocrit [Hct], and/or hemoglobin [Hb] levels) in rats (females only) treated at 1,250 mg/kg-day for up to 96 days Biodynamics, 1990a as cited in U.S. EPA (2009c) and in dogs treated at ≥250 mg/kg-day for 90 days Biodynamics, 1990b as cited in U.S. EPA (2009c).

There are limited data for hematological effects following inhalation exposure to members of the aromatic medium carbon range fraction. Figure B-11 is an exposure-response array containing studies for which hematological effects levels could be reliably determined. No significant, treatment-related hematological effects were observed in rats or mice exposed to isopropylbenzene at up to 907 mg/m^3^ for 14 weeks Ntp (2009). Rats exposed to TMB isomers (1,2,4- and 1,2,3-TMB) at ≥88 mg/m^3^ showed decreased clotting time, decreased segmented neutrophils, decreased RBCs, and/or changes in differential white blood cell (WBC) counts Korsak et al. 2000a, b as cited in U.S. EPA (2016b). Effects consistent with anemia (decreased Hct and mean corpuscular volume [MCV]) were reported in mice exposed to HFAN at 1,858 mg/m^3^ (highest concentration tested) on GDs 6–15 McKee et al., 1990 as cited in U.S. EPA (2009c); in contrast, a different study in rats reported no hematological effects following 12 months of exposure to HFAN at concentrations up to approximately 300 mg/m^3^ Clark et al., 1989 as cited in U.S. EPA (2009c).

Figure B-10 Hematological Effects in Animals after Oral Exposure to Aromatic Medium Carbon Range Compounds

Figure B-11 Hematological Effects in Animals after Inhalation Exposure to Aromatic Medium Carbon Range Compounds

Table Description automatically generated

### Summary of Potentially Relevant Evidence

Available data indicate that hematological effects associated with oral or inhalation exposure to TMBs (and HFAN) include changes in blood clotting parameters and other effects consistent with the development of anemia. Limited data are available for the other members of the fraction. Although available human data suggest that exposure to TMBs induces these effects, human data are insufficient to establish causal relationships (owing to coexposures with other compounds). In oral toxicity studies, rats treated with 1,3,5-TMB (at ≥143 mg/kg-day) and rats and dogs treated with HFAN (at 1,250 and ≥250 mg/kg-day, respectively) for 90–96 days showed increased monocytes and decreased Hct, Hb, and/or RBC counts (but no effects were reported in rats treated with HFAN or 1,4-DEB at lower doses). Rats exposed via inhalation to 1,2,4- or 1,2,3-TMB (at adjusted concentrations of ≥88 mg/m^3^) and mice exposed to HFAN (at 1,858 mg/m^3^ during gestation) showed similar types of effects (including decreased RBC counts, Hct, and MCV; and effects on differential WBC counts and clotting parameters), but no significant effects were reported after exposures of similar duration to isopropylbenzene. Taken together, the data suggest that at least some members of the aromatic medium carbon range fraction have the potential to induce anemia-like hematological effects. However, owing to the scarcity of data, it is not possible to evaluate the consistency in these endpoints and their potencies across members of the fraction.

## ENDOCRINE EFFECTS

An endocrine endpoint (increased adrenal weight) is the cocritical effect (with increased kidney weight) for the chronic p-RfC for isopropylbenzene U.S. EPA (1997). No human data pertaining to the endocrine effects of aromatic medium carbon range fraction members were identified. As shown in Table 5, data (oral or inhalation) on endocrine effects in animals were located for five members of the fraction. The endpoints evaluated in the studies were organ weight and histology (adrenals, thyroid, parathyroid, and/or pituitary).

### Human Studies

No human studies were available to address the potential for endocrine effects for any members of the aromatic medium carbon range fraction by any route of exposure.

### Animal Studies

Studies that identify reliable effect levels for endocrine effects following oral exposure are limited to two members of the aromatic medium carbon range fraction. Significantly increased absolute and/or relative adrenal gland weights were reported in F_1_ female rats treated with n-butylbenzene at 300 mg/kg-day for two generations Izumi, 2005 as cited in U.S. EPA (2010) and in female rats treated with HFAN at 893 mg/kg-day for 13 weeks Mobil Oil Company, 1994 as cited in U.S. EPA (2009c). In the former study, changes in adrenal gland weights occurred in the absence of histopathological changes; in the latter study, the adrenal glands were not examined microscopically, although the study authors performed gross necropsies on all animals and weighed major organs including the adrenal glands.

Data regarding endocrine effects from inhalation exposure to the aromatic medium carbon range compounds were identified for three members of the fraction. Based on organ weights and/or histopathology, there were no significant, treatment-related endocrine effects reported in rats or mice exposed to isopropylbenzene at up to 907 mg/m^3^ for 14 or 105 weeks (including microscopic evaluations of the adrenals, pituitary, thyroid, and parathyroid) Ntp (2009) or rats exposed to 1,2,4- or 1,2,3-TMB at up to 220 mg/m^3^ for 3 months (including adrenal weights and histopathology) Korsak et al., 2000a, b as cited in U.S. EPA (2016b). However, absolute and relative adrenal gland weights were significantly increased in male and female rats following exposure to isopropylbenzene at 1,055 mg/m^3^ for 13 weeks Cushman et al., 1995 as cited in U.S. EPA (1997).

### Summary of Potentially Relevant Evidence

Data from animal toxicity studies suggest that members of the aromatic medium carbon range fraction induce effects on the endocrine system (specifically, increased adrenal gland weights). In oral toxicity studies, rats treated with n-butylbenzene at 300 mg/kg-day showed increased adrenal weights (in the absence of significant histological effects); rats treated with HFAN at 893 mg/kg-day also showed increased adrenal weights (histology was not evaluated). Oral data were not available for other members of the fraction. Data for endocrine effects via the inhalation route of exposure were limited to studies of isopropylbenzene and two isomers of TMB. 1,2,4- and 1,2,3-TMB induced no significant changes in adrenal gland weights or histopathology in rats. Comprehensive subchronic and chronic studies of isopropylbenzene in rats and mice (at exposures up to 907 mg/m^3^) also failed to identify significant endocrine effects (including histological examinations of multiple endocrine organs). However, significantly increased adrenal gland weights were reported in rats exposed to a higher concentration of isopropylbenzene (1,055 mg/m^3^) for 13 weeks. Taken together, the data suggest that at least some members of the aromatic medium carbon range fraction have the potential to induce endocrine effects (increased adrenal weights). However, owing to the scarcity of data, it is not possible to evaluate the consistency in these endpoints and their potencies across members of the fraction.

## RESPIRATORY EFFECTS

None of the toxicity values for members of the aromatic medium carbon range fraction identify respiratory effects as the critical effect. Respiratory effects (mainly irritative effects) have been reported for humans occupationally exposed to solvents including TMBs; respiratory toxicity cannot be attributed to specific isomers. Respiratory toxicity data in humans are limited to TMBs; there are no data for most members of the aromatic medium carbon range fraction. Animal studies examining respiratory tract endpoints are available for five compounds (see Table 5); the preponderance of the animal data is from subchronic or chronic inhalation studies.

### Human Studies

There is evidence for respiratory toxicity in humans from occupational and residential studies involving inhalation exposure to complex volatile organic compound (VOC) mixtures that include TMBs, but the effects cannot be attributed to any individual compound. Occupational exposure to complex VOC mixtures containing TMB isomers has been associated with respiratory irritation, including laryngeal and/or pharyngeal irritation and asthmatic bronchitis U.S. EPA (2016b). Residential exposure to mixtures containing 1,2,4-TMB were observed to be associated with an increase in asthma; however, as these studies involved exposures to mixtures containing multiple TMB isomers and other VOCs, it is difficult to ascertain the specific contribution of each TMB isomer to the specific health effects reported. U.S. EPA (2016b). Multiple studies in volunteers involving controlled acute (<4 hours) inhalation exposures to TMB isomers up to 25 ppm (123 mg/m^3^) have not reported substantial irritation of the respiratory tract U.S. EPA (2016b). Studies of occupational and residential exposure to complex VOC mixtures suggest an association with asthmatic symptoms and sensory irritation; however, because these exposures are to complex mixtures, the effects cannot be attributed to any specific constituent U.S. EPA (2016b).

### Animal Studies

None of the available oral studies of compounds or mixtures relevant to the aromatic medium carbon range fraction examined respiratory tract effects in animals.

Data describing respiratory effects following inhalation exposure in animals for four members of the aromatic medium carbon range fraction were identified. Changes in the composition of the bronchoalveolar lavage (BAL) fluid were observed following inhalation exposure of rats to 1-methyl-4-ethylbenzene at 417 mg/m^3^ for 4 weeks; this effect was accompanied by changes in lung histopathology (i.e., bronchitis, bronchopneumonia, and perivascular lymphocyte infiltration) Swiercz et al. (2000). Histopathological lesions were also observed in animals exposed to isopropylbenzene, 1,2,4-TMB, and 1,2,3-TMB. Increased incidences of hyperplasia of the nose (olfactory and respiratory epithelia) were reported in rats exposed to isopropylbenzene at ≥227 mg/m^3^ for 105 weeks. Mice similarly exposed to isopropylbenzene showed lesions (metaplasia of the alveolar epithelium and bronchiole in the lung, accompanied by atrophy and hyperplasia in the nasal passages at higher concentrations) at ≥227 mg/m^3^ (males) or ≥113 mg/m^3^ (females) Ntp (2009). Significantly increased incidences of lesions of the lower respiratory tract were also noted in rats exposed to TMBs at ≥88 mg/m^3^ for 3 months Korsak et al., 2000a, 2000b as cited in U.S. EPA (2016b). No respiratory tract lesions were observed in rats or rabbits exposed to high concentrations of isopropylbenzene (up to 1,488 mg/m^3^ in rats and 2,823 mg/m^3^ in rabbits) during gestation Darmer et al. (1997).

### Summary of Potentially Relevant Evidence

Irritative effects and asthma have been reported in humans exposed to VOC mixtures containing TMBs; however, data are insufficient to attribute these effects to TMB isomers (owing to coexposures to other compounds). No animal oral data are available for any members of the aromatic medium carbon range fraction. In inhalation studies, changes in respiratory tract pathology (such as hypertrophy of the nose, metaplasia, bronchitis, bronchopneumonia in the lung) were reported following exposures to four members of the fraction (isopropylbenzene, 1-methyl-4-ethylbenzene, and 1,2,4- and 1,2,3-TMB); LOAELs for these effects ranged between 88 and 417 mg/m^3^ in rats and mice. There are insufficient data to determine if respiratory effects are consistently associated with oral or inhalation exposure to members of the aromatic medium carbon range fraction.

## DEVELOPMENTAL EFFECTS

Developmental toxicity is the critical effect for the n-propylbenzene subchronic and chronic p-RfCs U.S. EPA (2009d). The EPA’s p-RfCs for n-propylbenzene were developed using a read-across approach where ethylbenzene was the selected analogue.

For members of this fraction, there are no suitable human data on developmental toxicity. Studies (oral or inhalation) examining developmental endpoints in animals are available for five compounds and one mixture relevant to the aromatic medium carbon range fraction.

### Human Studies

Occupational exposure to or inhalant abuse of solvents that may contain TMBs by pregnant women results in a range of cognitive, behavioral, and visual dysfunctions among their children; however, the effects cannot be solely attributed to TMBs U.S. EPA (2016b).

### Animal Studies

There are available data regarding developmental effects following oral exposure for three members of the aromatic medium carbon range fraction. No significant effects on development (based on evaluations of fetal body weights and external examinations of fetuses) were reported in rats treated with 1,4-DEB at up to 750 mg/kg-day for 6 weeks MHW, 1993b as cited in Oecd (1994). Increased thymus weight was noted in female F_2_ offspring of rats treated with n-butylbenzene at 300 mg/kg-day; other reproductive/developmental parameters evaluated in the same two-generation study (including fertility and litter endpoints) were unaffected by treatment Izumi, 2005 as cited in U.S. EPA (2010). Decreased fetal body weights and delayed skeletal ossification (incompletely or unossified thoracic vertebral centrum and sacral vertebral transverse processes) were observed following treatment of dams with HFAN at 1,250 mg/kg-day on GDs 6–15 Biodynamics, 1990c as cited in U.S. EPA (2009c).

Developmental toxicity studies via inhalation are available for four members of the aromatic medium carbon range fraction (isopropylbenzene, 1,3,5- and 1,2,4-TMB, and HFAN); significant effects were reported for each compound. Figure B-12 is an exposure-response array containing studies for which effects levels could be reliably determined. In rabbits exposed to isopropylbenzene at 2,823 mg/m^3^ on GDs 6–18, increased numbers of nonviable implants and resorptions, and a decreased percentage of live fetuses were reported (not statistically significant but considered biologically significant based on the U.S. EPA assessment under the IRIS program) Darmer et al. (1997). Developmental parameters were unaffected in rats similarly exposed to isopropylbenzene at up to 1,488 mg/m^3^ on GDs 6–15 Darmer et al. (1997). Reductions in fetal body weights were observed in rats following exposure to TMB isomers at ≥738 mg/m^3^ on GDs 6–20 Saillenfait et al., as cited in U.S. EPA (2016b). Fetal mortality, decreased fetal body weights, or delayed skeletal development were reported following exposures to HFAN. Rabbit dams treated at 1,000 mg/m^3^ on GDs 7–20 showed complete abortion Ungvary and Tatrai, 1985 as cited in U.S. EPA (2009c), mice exposed at ≥613 mg/m^3^ on GDs 6–15 showed decreased fetal body weights McKee et al., 1990 as cited in U.S. EPA (2009c), rats exposed at ≥434 mg/m^3^ for three generations showed decreased pup weights during lactation McKee et al., 1990 as cited in U.S. EPA (2009c), and rats treated at 600 mg/m^3^ on GDs 7–15 showed delays in skeletal ossification Ungvary and Tatrai, 1985 as cited in U.S. EPA (2009c). In another study, neurobehavior was not significantly impacted in the offspring of rats treated with HFAN at up to 500 mg/m^3^ on GDs 7–15 Lehotsky et al., 1985 as cited in U.S. EPA (2009c).

Figure B-12 Developmental Effects in Animals after Inhalation Exposure to Aromatic Medium Carbon Range

### Summary of Potentially Relevant Evidence

Data from human studies indicate that exposure to solvents (presumably including members of the aromatic medium carbon range fraction) causes behavioral changes and visual and cognitive impairments. These data are insufficient to determine the specific role of aromatic medium carbon range compounds in the induction of these effects in humans. There are animal data (oral or inhalation) for six members of the fraction. Animal studies have identified effects (increased thymus weights) in rats orally exposed to n-butylbenzene (LOAEL of 300 mg/kg-day) and HFAN (decreased fetal body weights, delayed skeletal development) (LOAEL of 1,250 mg/kg-day). No significant effects on development were reported in rats treated with 1,4-DEB at up to 750 mg/kg-day. Inhalation toxicity studies of HFAN have likewise identified developmental effects (including decreased fetal/pup body weights and delayed skeletal ossification in rats, decreased fetal body weights in mice, and fetal death in rabbits). Similar effects (decreased numbers of live fetuses following isopropylbenzene exposure, and decreased body weights of offspring following 1,3,5- and 1,2,4-TMB exposure) were also identified after inhalation exposures to other members of the aromatic medium carbon range fraction. Lowest LOAELs (by compound or mixture) for these effects ranged from 434 to 738 mg/m^3^ in rats and from 1,000 to 2,823 mg/m^3^ in rabbits; a LOAEL of 613 mg/m^3^ was identified for HFAN in mice (see Figure B-12). Taken together, data from oral and inhalation developmental toxicity studies consistently identify decreased fetal body weights for several members of the aromatic medium carbon range fraction.

## OTHER EFFECTS

New studies identified in the PubMed searches identified reproductive effects in rats and mice exposed to isopropylbenzene by inhalation. The National Toxicology Program Ntp (2009) reported significant changes in the relative length of time spent in estrous and proestrus in treated female rats treated with isopropylbenzene for 14 weeks. In the same report, male mice treated at 907 mg/m^3^ (also for 14 weeks) showed significant reductions in cauda epididymis weight and spermatid count. No other studies of sperm or estrous cycle parameters in humans or animals exposed to aromatic medium carbon range compounds or mixtures were located in the sources reviewed.