# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGERS

- Glenn E. Rice, ScD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

- Allison L. Phillips, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

## CONTRIBUTOR

- Elizabeth O. Owens, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

- Jacqueline Weinberger, Student Services Contractor
  Oak Ridge Associated Universities

## DRAFT DOCUMENT PREPARED BY

- SRC, Inc.
  7502 Round Pond Road
  North Syracuse, NY 13212

## PRIMARY INTERNAL REVIEWERS

- Jeffry L. Dean II, PhD
  Center for Public Health and Environmental Assessment, Cincinnati, OH

- M. Margaret Pratt, PhD
  Center for Public Health and Environmental Assessment, Washington, DC

## PRIMARY EXTERNAL REVIEWERS

- Eastern Research Group, Inc.
  110 Hartwell Avenue
  Lexington, MA 02421-3136

## PPRTV PROGRAM MANAGEMENT

- Teresa L. Shannon
  Center for Public Health and Environmental Assessment, Cincinnati, OH

- J. Phillip Kaiser, PhD, DABT
  Center for Public Health and Environmental Assessment, Cincinnati, OH

Questions regarding the content of this PPRTV assessment should be directed to the U.S. EPA Office of Research and Development (ORD) Center for Public Health and Environmental Assessment (CPHEA) website at https://ecomments.epa.gov/pprtv.