# 6 DERIVATION OF PROVISIONAL VALUES

## 6.1 DERIVATION OF ORAL REFERENCE DOSES

Tables 6 and 7 summarize the subchronic and chronic reference values for constituent compounds, respectively, with points of departure (PODs), uncertainty factors, critical endpoints, and confidence ratings.

Table 6 Available Subchronic RfD Values for Aromatic High Carbon Range Fraction (C10–C32, EC11–EC35)^a^

Indicator Chemical or Components | POD (mg/kg-d) | POD Type | UFc | UF Components | p-RfD (mg/kg-d) | Confidence in p-RfD | Critical Effect(s) | Species, Mode, and Duration | Reference
Benzo[a]pyrene^b^ (C20 [EC29.95]) | 0.092 | BMDL | 300 | UF_A_, UF_D_, UF_H_ | 0.0003 | Medium | Neurobehavioral changes (developmental) | Rat, gavage, PNDs 5–11 | Chen et al. (2012) as cited in U.S. EPA (2017a)
Benzo[e]pyrene (C20 [EC27.80]) | 0.092 | BMDL | 1,000 | UF_A_, UF_D_, UF_H_ | 0.00009 ^c^ | NA | Based on benzo[a]pyrene as an analogue; neurobehavioral changes (developmental) | Rat, gavage, PNDs 5–11 | U.S. EPA (2021b)
Naphthalene (C10 [EC11.57]) | 50 | LOAEL | 90 | UF_A_, UF_H_, UF_L_ | 0.6 | NA | Clinical signs of toxicity and decreased body-weight gain (whole body effects) | Rat, gavage, GDs 6–15 | NTP (1991) as cited in ATSDR (2005)
2-Methylnaphthalene (C11 [EC12.72]) | 3.5 | BMDL_05_ | 1,000 | UF_A_, UF_D_, UF_H_ | 0.004^c^ | Low | Pulmonary alveolar proteinosis (respiratory) | Mouse, diet, 81 wk | Murata et al (1997) as cited in U.S. EPA (2007a)
1,1-Biphenyl (C12 [EC13.45]) | 9.59 | BMDL_05_ | 100 | UF_A_, UF_H_ | 0.1^c^ | High | Increased incidence of fetal skeletal anomalies (developmental) | Rat, gavage, GDs 6–15 | Khera et al. (1979) as cited in U.S. EPA (2011a)
Acenaphthene (C12 [EC14.76]) | 161 | BMDL_10_ | 1,000 | UF_A_, UF_D_, UF_H_ | 0.2^c^ | Low | Increased relative liver weight (hepatic) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (2011b)
Fluorene (C13 [EC15.68]) | 125 | LOAEL | 300 | UF_A_, UF_H_, UF_L_ | 0.4 | NA | Increased relative liver weight (hepatic) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in ATSDR (1995)
Anthracene (C14 [EC18.43]) | 1,000 | NOEL | 1,000 | UF_A_, UF_D_, UF_H_ | 1^c^ | Low | No effects observed | Mouse, gavage, 13 wk | Wolfe (1989) as cited in U.S. EPA (2009a)
Pyrene (C16 [EC22.45]) | 75 | NOAEL | 300 | UF_A_, UF_D_, UF_H_ | 0.3^c^ | Low | Nephropathy and decreased kidney weights (urinary) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (2007b)
Fluoranthene (C16 [EC21.11]) | 124 | BMDL_10_ | 1,000 | UF_A_, UF_D_, UF_H_ | 0.1^c^ | Low | Nephropathy (urinary) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (2012)

a Bolded row shows the compound and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b The chronic RfD for benzo[a]pyrene is based on a developmental exposure; therefore, it is also applicable to subchronic exposures and is listed here.

c Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening provisional values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

BMDL = benchmark dose lower confidence limit; BMDL_05_ = 5% benchmark dose lower confidence limit; BMDL_10_ = 10% benchmark dose lower confidence limit; C = carbon; EC = equivalent carbon; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NA = not applicable, reference did not include confidence statement; NOAEL = no-observed-adverse-effect level; NOEL = no-observed-effect level; PND = postnatal day; POD = point of departure; PPRTV = Provisional Peer-Reviewed Toxicity Value; p-RfD = provisional reference dose; RfD = reference dose; SD = standard deviation; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor.

Table 7 Available Chronic RfD Values for Aromatic High Carbon Range Fraction (C10–C32, EC11–EC35)^a^

Indicator Chemical or Components | POD (mg/kg-d) | POD Type | UFc | UF Components | p-RfD or RfD (mg/kg-d) | Confidence in p-RfD or RfD | Critical Effect(s) | Species, Mode, and Duration | Reference
Benzo[a]pyrene^b^ (C20 [EC29.95]) | 0.092 | BMDL | 300 | UF_A_,^c^ UF_D_, UF_H_ | 0.0003 | Medium | Neurobehavioral changes (developmental) | Rat, gavage, PNDs 5–11 | Chen et al. (2012) as cited in U.S. EPA (2017a)
Benzo[e]pyrene (C20 [EC27.80]) | 0.092 | BMDL | 1,000 | UF_A_, UF_D_, UF_H_ | 0.00009 ^d^ | NA | Based on benzo[a]pyrene as an analogue; neurobehavioral changes (developmental) | Rat, gavage, PNDs 5–11 | U.S. EPA (2021b) (in review)
Naphthalene (C10 [EC11.57]) | 71 | NOAEL_ADJ_ | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.02 | Low | Decreased mean terminal body weight (other) | Rat, gavage, 5 d/wk, 13 wk | BCL (1980) as cited in U.S. EPA (1998)
2-Methylnaphthalene (C11 [EC12.72]) | 3.5 | BMDL_05_ | 1,000 | UF_A_, UF_D_, UF_H_ | 0.004 | Low | Pulmonary alveolar proteinosis (respiratory) | Mouse, diet, 81 wk | Mureta et al. (1997) as cited in U.S. EPA (2003)
1-Methylnaphthalene (C11 [EC12.77]) | 71.6 | LOAEL | 10,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.007 ^d^ | Low | Pulmonary alveolar proteinosis (respiratory) | Mouse, diet, 81 wk | Mureta et al. (1993) as cited in U.S. EPA (2008)
1,1-Biphenyl (C12 [EC13.45]) | 13.9 | BMDL_10_ (HED) | 30 | UF_A_, UF_H_ | 0.5 | Medium-high | Renal papillary mineralization in males F344 rats (urinary) | Rat, diet, 104 wk | Umeda et al. (2002) as cited in U.S. EPA (2013)
Acenaphthene (C12 [EC14.76]) | 175 | NOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.06 | Low | Hepatotoxicity (hepatic) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (1990a)
Fluorene (C13 [EC15.68]) | 125 | NOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.04 | Low | Decreased RBCs, packed cell volume, and hemoglobin (hematologic) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (1990d)
Anthracene (C14 [EC18.43]) | 1,000 | NOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.3 | Low | No effects observed | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (1990b)
Pyrene (C16 [EC22.45]) | 75 | NOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.03 | Low | Kidney effects (renal tubular pathology, decreased kidney weights) (urinary) | Mouse, gavage, 13 wk | U.S. EPA (1989) as cited in U.S. EPA (1990e)
Fluoranthene (C16 [EC21.11]) | 125 | NOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.04 | Low | Nephropathy, increased liver weights, hematological alterations, and clinical effects (hepatic, urinary) | Mouse, gavage, 13 wk | U.S. EPA (1988) as cited in U.S. EPA (1990c)

a Bolded rows show the compound and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b The chronic RfD for benzo[a]pyrene is based on a developmental exposure.

c Body-weight scaling to derive an HED was not performed because doses were administered directly to early postnatal animals (U.S. EPA, 2017a).

d Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening provisional values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

ADJ = adjusted; BMDL = benchmark dose lower confidence limit; BMDL_05_ = 5% benchmark dose lower confidence limit; BMDL_10_ = 10% benchmark dose lower confidence limit; C = carbon; EC = equivalent carbon; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; p-RfD = provisional reference dose; PND = postnatal day; POD = point of departure; PPRTV = provisional peer-reviewed toxicity value; RBC = red blood cell; RfD = reference dose; SD = standard deviation; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

Subchronic provisional reference doses (p-RfDs) and a subchronic RfD are available for 10 compounds in the fraction (see Table 6). It should be noted that the chronic RfD for BaP is based on a developmental exposure, which is also applicable to subchronic exposures; accordingly, the chronic RfD value for BaP is listed in Tables 4 and 6 as a proxy for subchronic exposure. As a result of the limitations of the available oral toxicity data for BeP, the U.S. EPA did not directly derive a subchronic p-RfD. Instead, a screening subchronic p-RfD is derived in the U.S. EPA PPRTV assessment document, using an alternative analogue approach based on the RfD for BaP (U.S. EPA, 2017a). The critical endpoints for the other subchronic p-RfDs are clinical signs of toxicity and decreased body-weight gain (naphthalene), lung toxicity (2-methylnaphthalene), developmental effects (1,1-biphenyl), liver effects (acenaphthene, fluorene), and kidney toxicity (pyrene, fluoranthene). The subchronic p-RfD for anthracene is based on a lack of effects.

There are 11 available chronic p-RfDs or RfDs for constituent compounds (see Table 7). The critical endpoints for these chronic RfDs are decreased body weight (naphthalene), lung toxicity (1-methylnaphthalene, 2-methylnaphthalene), kidney toxicity (1,1-biphenyl, pyrene, fluoranthene), liver effects (acenaphthene, fluoranthene), hematological effects (fluorene, fluoranthene), and developmental neurotoxicity (BaP, BeP). The chronic RfD for anthracene is based on a lack of effects.

As suggested by the disparity in critical endpoints and values of RfDs for fraction members and discussed in Section 3 (and Appendix C), the available oral toxicity data for aromatic high carbon range compounds do not show much consistency across fraction members in terms of similarity in critical or sensitive effects and potencies. There is no basis to identify a surrogate mixture or compound that is representative of the effects and potency of the fraction as a whole. Therefore, the compounds that resulted in the lowest RfDs were considered as the basis for indicator chemical selection (see Section 2.3).

### 6.1.1 Oral Noncancer Assessment Using the Indicator Chemical Method for the Aromatic High Carbon Range Fraction

The lowest oral subchronic and chronic RfD among the compounds in this fraction that are not screening values is the chronic RfD for BaP (see Tables 6 and 7); this value is recommended for chronic exposures to the aromatic high carbon range fraction if available analytical chemistry data do not identify concentrations of individual chemicals composing this fraction, and an indicator chemical approach is implemented. Although a subchronic toxicity value is not available for BaP, the chronic RfD is based on a developmental exposure, so the RfD value is applicable to subchronic exposures as well, if an indicator approach is implemented. Accordingly, the chronic RfD for BaP is listed in Table 6 as an available subchronic oral toxicity value for constituents in the aromatic high carbon range fraction. Subchronic and chronic toxicity values for several other PAHs in this fraction are considerably higher (several orders of magnitude in some cases) than the chronic RfD for BaP, raising the question of whether use of BaP as the indicator chemical for the fraction may be toxicologically relevant. However, emerging information on mixtures and other compounds shows effects at exposures comparable to (or even lower than) levels at which BaP induces toxicity, suggesting that use of BaP values for the whole fraction may be more appropriate than implied by comparisons limited to compounds with toxicity values. For example, recent studies suggest that other PAHs may induce altered reproductive tract development (Kim et al., 2011), neurodevelopmental effects (Crepeaux et al., 2014, 2013, 2012), transgenerational changes in immune function (Chu et al., 2013), adiposity (Yan et al., 2014), or lethal transplacental carcinogenesis (Madeen et al., 2016; Benninghoff and Williams, 2013; Shorey et al., 2013; Shorey et al., 2012; Castro et al., 2009;Castro et al., 2008c; Castro et al., 2008a; Castro et al., 2008b) at very low exposure levels. These newer studies support the selection of BaP as the indicator chemical because it is the only indicator chemical candidate with an oral toxicity value that will be protective against most of these effects. However, users of the indicator chemical method should understand that there could be more uncertainty associated with the application of this toxicity value to the aromatic high carbon range fraction than for its derivation in U.S. EPA (2017a).

The IRIS review of BaP (U.S. EPA, 2017b) cited Chen et al. (2012) as the principal study for the chronic RfD. The supplemental information for the toxicological review of BaP (U.S. EPA, 2017b) provided the following summary.

Chen et al. (2012) treated male and female neonatal Sprague-Dawley rats (10/sex/group) with benzo[a]pyrene (unspecified purity) dissolved in peanut oil by gavage daily on PNDs 5−11, at doses of 0.02, 0.2, or 2 mg/kg in 3 mL vehicle/kg body weight, determined individually based upon daily measurements. This time period was described as representing the brain growth spurt in rodents, analogous to brain developmental occurring from the third trimester to 2 years of age in human infants. Breeding was performed by pairs of 9-week-old rats, with delivery designated as PND 0. Litters were culled to eight pups/dam (four males and four females, when possible) and randomly redistributed at PND 1 among the nursing dams; dams themselves were rotated every 2−3 days to control for caretaking differences, and cage-side observations of maternal behavior were made daily. One male and female from each litter were assigned per treatment group, and the following physical maturation landmarks were assessed daily in all treatment groups until weaning at PND 21: incisor eruption, eye opening, development of fur, testis decent, and vaginal opening.

Neonatal sensory and motor developmental tests were administered to pups during the preweaning period at PNDs 12, 14, 16, and 18, and were behavioral tests administered to rats as adolescents (PNDs 35 and 36) or as adults (PNDs 70 and 71): each rat was only tested during one developmental period. All dosing was performed from 1300 to 1600 hours, and behavioral testing was during the “dark” period from 1900 to 2300 hours, although tests were performed in a lighted environment. Pups were observed individually and weighed daily, the order of testing litters was randomized each day, and all observations were recorded by investigators blinded to group treatment.

Sensory and motor developmental tests, including the surface righting reflex test, negative geotaxis test, and cliff aversion test, were performed only once, while the forelimb grip strength test was assessed during three 60-second trials on PND 12. Rat movements during the open-field test were recorded by camera, and two blinded investigators scored movement and rearing separately during a 5-minute evaluation period. Blinded investigators directly observed video monitoring of rat movements during the elevated plus maze, and after a 5-minute free exploration period, recorded number of entries into the closed and open arms, time spent in the open arms, and latency to the first arm entry. Assessment of the Morris water maze was slightly different, in that the rats were habituated to the testing pool by a 60-second swim without a platform on the day prior to testing. The rats were then tested during a 60-second swim with a hidden platform present at a constant position each day for 4 days; on the 5th day, the rats were evaluated during a 60-second probe swim without a platform. The number of times each animal crossed the original platform location and the duration of time spent in the platform quadrant were recorded during this final evaluation. One pup/sex/litter were assigned for behavioral testing to each of four tracks: Track 1, surface righting reflex test, cliff aversion test, and open-field test (PNDs 12−18); Track 2, negative geotaxis test, forelimb grip strength test, and open-field test (PNDs 12−20); Track 3, elevated plus maze, Morris water maze, and open-field test (PNDs 34−36); and Track 4, elevated plus maze, Morris water maze, and open-field test (PNDs 69−71). All results were presented in graphic form only.

No significant effects on pup body weight were observed during the 7-day treatment period (PNDs 5−11). Three-way ANOVA (time × benzo[a]pyrene treatment × sex) indicated that effects of benzo[a]pyrene were not sex-dependent throughout the 71-day experiment, so both sexes were pooled together. From this pooled analysis, pups in the 2 mg/kg-day treatment group gained significantly less weight at both PND 36 and 71. There were no differences among treatment groups in incisor eruption, eye opening, development of fur, testis decent, or vaginal opening.

For all measurements of neonatal sensory and motor development, results from both sexes were analyzed together since benzo[a]pyrene was reported to have no significant interaction with sex by 3-way ANOVA. No significant differences were observed in either the cliff aversion or forelimb grip strength tests. In the surface righting reflex test, latency was increased in the 0.2 mg/kg-day group at PND 12, in the 0.02 and 2 mg/kg-day groups at PND 14, and in only the high-dose group at PND 16; latency was not significantly different in any group at PND 18. At PND 12, there was a dose-related increase in negative geotaxis latency associated with 0.02, 2, and 2 mg/kg-day benzo[a]pyrene, which was also present in the 2 mg/kg-day group at PND 14, but returned to control levels at PND 16 and 18. In the open field test, there were no significant differences in either locomotion or rearing activity at PND 18 or 20. At PND 34, the 2 mg/kg-day group exhibited significantly increased movement, but increases in rearing were not significant. At PND 69, increased locomotion was observed in both the 0.2 and 2 mg/kg-day groups, while rearing was significantly increased in only the 2 mg/kg-day treatment group.

The elevated plus maze performance was only evaluated in adolescent and adult rats. Unlike the previous tests, 3-way ANOVA revealed a statistically significant interaction between neonatal benzo[a]pyrene treatment and sex, so male and female performance was analyzed independently. No significant differences in PND 35 males were observed, and the only significant observation in PND 35 females was increased time spent in the open maze arms by the 2 mg/kg-day treatment group. Significantly decreased latency time to first open arm entry was observed in PND 70 males and females in both 0.2 and 2 mg/kg-day treatment groups; these groups also spent significantly more time in open maze arms, along with the 0.02 mg/kg-day female group. At PND 70, the 2 mg/kg-day males, along with the 0.2 and 2 mg/kg-day females, entered more frequently into open arms and less frequently into closed arms than the vehicle controls. In the Morris water maze, escape latency (time to reach the platform during each of the four testing days) was consistently increased in the 2 mg/kg-day treatment group of both sexes, in both adolescent and adult animals. These increases were statistically significant in both males and females treated with 2 mg/kg-day benzo[a]pyrene at both PNDs 39 and 74, and were also significantly elevated in 0.2 mg/kg-day animals of both sexes at PND 74. Likewise, performance during the 5th test day, in the absence of the escape platform, was significantly adversely affected by both metrics (decreased time spent in the target quadrant and decreased number of attempts to cross the platform location) in 2 mg/kg-day rats of both sexes at both PNDs 40 and 75. PND 75 females treated with 0.2 mg/kg-day benzo[a]pyrene also showed significant decreases in both performance metrics, while PND 75 0.2 mg/kg-day males only demonstrated significant differences in “time spent in target quadrant.” Swim speed was also assessed, but there were no differences among any treatment group at either age evaluated.

### 6.1.2 Alternative Oral Noncancer Assessment Using the Hazard Index Method for the Aromatic Medium Carbon Range Fraction

If the available analytical chemistry data quantify the concentrations of naphthalene, 2-methylnapthlalene, 1-methylnapthalene, 1,1-biphenyl, acenaphthene, fluorene, anthracene, pyrene, fluoranthene, or BaP separately from the remainder of the aromatic high carbon range fraction, it is recommended that HQs for the individual chemicals with existing analytical data be calculated and an HI for the mixture be developed using the calculated HQs.

For subchronic oral exposures, the subchronic RfDs or p-RfDs as shown in Table 6 can be used as the denominator in the HQ equations. Additionally, the chronic RfD for BaP (0.0003 mg/kg-day) can be adopted for subchronic exposures because it is based on a developmental study (as discussed above). In this alternative approach, the chronic RfD for BaP (0.0003 mg/kg-day) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually (see Table 6).

For chronic oral exposures, the chronic RfDs or p-RfDs as shown in Table 7 can be used as the denominator in the HQ equations. In this alternative approach, the chronic RfD for BaP (0.0003 mg/kg-day) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually (see Table 7).

## 6.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

The available subchronic and chronic RfC values, with PODs, uncertainty factors, endpoints, and confidence ratings, are presented in Table 8. As shown in the table, there are two subchronic screening p-RfCs (1,1-biphenyl and BeP), one subchronic RfC (BaP), two chronic screening p-RfCs (1,1-biphenyl and BeP), and two chronic p-RfC or RfC values (naphthalene and BaP). Critical effects for the aforementioned RfCs include liver and kidney toxicity (1,1-biphenyl), nasal lesions (naphthalene), and developmental toxicity (BaP and BeP).

Table 8 Available RfC Values for Aromatic High Carbon Range Fraction (C10–C32, EC11–EC35)^a^

Indicator Chemical or Components | POD (mg/m^3^) | POD Type (HEC) | UFc | UF Components | p-RfC or RfC (mg/m^3^) | Confidence in p-RfC or RfC | Critical Effect(s) | Species, Frequency, and Duration | Reference
Subchronic
1,1-Biphenyl (C12 [EC13.45]) | 1.23 | BMCL_10_^b^ | 300 | UF_A_, UF_D_, UF_H_ | 0.004 ^c^ | Low | Congestion and edema of liver and kidneys (hepatic, urinary) | Mouse, 7 h/d, 5 d/wk for 13 wk | Cannon Laboratories Inc. (1977) as cited in U.S. EPA (2011a)
Benzo[a]pyrene^d^ (C20 [EC29.95]) | 0.0046 | LOAEL ^e^ | 3,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.000002 | Low-medium | Decreased embryo/fetal survival (developmental) | Rat, 4 h/d on GDs 11–20 | Archibong et al. (2002) as cited in U.S. EPA (2017a)
Benzo[e]pyrene (C20 [EC27.80] | 0.0046 | LOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.000002 ^c^ | Low | Based on benzo[a]pyrene as an analogue; decreased embryo/fetal survival (developmental) | Rat, 4 h/d on GDs 11–20 | Archibong et al. (2002) as cited in U.S. EPA (2021b)
Chronic
Naphthalene (C10 [EC11.57]) | 9.3 | LOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.003 | Low-medium | Nasal effects: hyperplasia and metaplasia in respiratory and olfactory epithelium, respectively (nervous, respiratory) | Mouse, 6 h/d, 5 d/wk for 2 yr | NTP (1992) as cited in U.S. EPA (1998)
1,1-Biphenyl (C12 [EC13.45]) | 1.23 | BMCL_10_ | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.0004 ^c^ | Low | Congestion and edema of liver and kidneys (hepatic, urinary) | Mouse, 6 h/d, 7 d/wk for 13 wk | Cannon Laboratories Inc. (1977) as cited in U.S. EPA (2011a)
Benzo[a]pyrene (C20 [EC29.95]) | 0.0046 | LOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.000002 | Low-medium | Decreased embryo/fetal survival (developmental) | Rat, 4 h/d on GDs 11–20 | Archibong et al. (2002) as cited in U.S. EPA (2017a)
Benzo[e]pyrene (C20 [EC27.80]) | 0.0046 | LOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.000002 ^c^ | NA | Based on benzo[a]pyrene as an analogue; decreased embryo/fetal survival (developmental) | Rat, 4 h/d on GDs 11–20 | Archibong et al. (2002) as cited in U.S. EPA (2021b)

a Bolded row shows the compound and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b U.S. EPA derived the HEC in a PPRTV based on consideration of the critical effect as extrarespiratory (using the RGDR for the extrarespiratory region).

c Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening provisional values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

d Because the chronic RfC for benzo[a]pyrene is based on a developmental exposure, it is also applicable to subchronic exposures and is listed here.

e U.S. EPA derived the HEC in an IRIS assessment based on consideration of the critical effect as extrarespiratory (using the RGDR for the extrarespiratory region).

BMCL_10_ = 10% benchmark concentration lower confidence limit; C = carbon; EC = equivalent carbon; GD = gestation day; HEC = human equivalent concentration; IRIS = Integrated Risk Information System; LOAEL = lowest-observed-adverse-effect level; NA = not applicable; POD = point of departure; PPRTV = Provisional Peer-Reviewed Toxicity Value; p-RfC = provisional reference concentration; RfC = reference concentration; RGDR = regional gas dose ratio; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor; U.S. EPA = U.S. Environmental Protection Agency.

As suggested by the disparity in critical endpoints and values of RfCs for fraction members and discussed in the following section, as well as in Appendix C, the available inhalation toxicity data for aromatic high carbon range compounds do not show much consistency across fraction members in terms of toxicological effects or potencies. Additionally, inhalation data are limited to four members of the fraction and one PAH mixture. There is no basis to identify a surrogate mixture or compound that is representative of the effects and potency of the fraction as a whole. Therefore, the compounds that resulted in the lowest RfCs were considered as the basis for indicator chemical selection (see Section 3).

### 6.2.1 Inhalation Noncancer Assessment the Indicator Chemical Method for the Aromatic High Carbon Range Fraction

The lowest RfC among the compounds in this fraction that is not a screening value is the chronic RfC for BaP (see Table 8); this value is recommended for chronic exposures to the aromatic high carbon range fraction if available analytical chemistry data do not identify concentrations of individual chemicals composing this fraction. Although a subchronic toxicity value is not available for BaP, the chronic RfC is based on a developmental exposure endpoint, so the RfC value is applicable to subchronic exposures as well. The few available subchronic and/or chronic toxicity values for other PAHs are considerably higher (>2 orders of magnitude) than the chronic RfC for BaP, raising the question of whether use of BaP as the indicator chemical for the fraction may be overly conservative. However, a mixtures study suggests that neurodevelopmental effects may occur at exposures lower than levels at which BaP induces toxicity (Slotkin et al., 2017), suggesting that use of BaP values for the whole fraction may be more appropriate than implied by comparisons limited to compounds with toxicity values. At this time, the database for members of this fraction and relevant mixtures that elicit neurodevelopmental effects is not comprehensive. Thus, BaP is considered an appropriate indicator because it has the lowest RfC among fraction members and the most comprehensive database. In addition, because neurodevelopmental effects are the critical effect for oral exposures to BaP, there is evidence that BaP can affect neurodevelopmental outcomes. However, users of the indicator chemical method should understand that there could be more uncertainty associated with the application of this toxicity value to the aromatic high carbon range fraction than for its derivation in U.S. EPA (2017a).

The IRIS review of BaP (U.S. EPA, 2017a) cited Archibong et al. (2002) as the principal study for the chronic RfC. The supplemental information for the toxicological review of BaP (U.S. EPA, 2017b) provided the following summary.

Archibong et al. (2002) evaluated the effect of exposure to inhaled benzo[a]pyrene on fetal survival and luteal maintenance in timed-pregnant F344 rats. Prior to exposure on GD 8, laparotomy was performed to determine the number of implantation sites, and confirmed pregnant rats were divided into three groups, consisting of rats that had four to six, seven to nine, or more than nine conceptuses in utero. Rats in these groups were then assigned randomly to the treatment groups or control groups to ensure a similar distribution of litter sizes. Animals (10/group) were exposed to benzo[a]pyrene:carbon black aerosols at concentrations of 25, 75, or 100 μg/m^3^ via nose-only inhalation, 4 hours/day on GDs 11−20. Control animals were either sham-exposed to carbon black or remained entirely unexposed. Results of particle size analysis of generated aerosols were reported by several other reports from this laboratory (Inyang et al., 2003; Ramesh et al., 2001a; Hood et al., 2000). Aerosols showed a trimodal distribution (average of cumulative mass, diameter) <95%, 15.85 μm; 89%, <10 μm; 55%, <2.5 μm; and 38%, <1 μm (Inyang et al., 2003). Ramesh et al. (2001a) reported that the MMAD (± geometric SD) for the 55% mass fraction with diameters <2.5 μm was 1.7 ± 0.085. Progesterone, estradiol-17β, and prolactin concentrations were determined in plasma collected on GDs 15 and 17. Fetal survival was calculated as the total number of pups divided by the number of all implantation sites determined on GD 8. Individual pup weights and crown-rump length per litter per treatment were determined on PND 4 (PND 0 = day of parturition).

Archibong et al. (2002) reported that exposure of rats to benzo[a]pyrene caused biologically and statistically significant (p ≤ 0.05) reductions in fetal survival compared with the two control groups; fetal survival rates were 78.3, 38.0, and 33.8% per litter at 25, 75, and 100 μg/m^3^, respectively, and 96.7% with carbon black or 98.8% per litter in untreated controls (see Table D-30). Consequently, the number of pups per litter was also decreased in a concentration-dependent manner. The decrease was ~50% at 75 μg/m^3^ and ~65% at 100 μg/m^3^, compared with sham-exposed and unexposed control groups. No effects on hormone levels were observed on GDs 15 or 17 at the low dose. Biologically significant decreases in mean pup weights (expressed as g per litter) of >5% relative to the untreated control group were observed at doses ≥75 μg/m^3^ (14 and 16% decreases at 75 and 100 μg/m^3^, respectively, p < 0.05). There were no statistically significant differences from the control groups in crown-rump length (see Table D-30).

Benzo[a]pyrene exposure at 75 μg/m^3^ caused a statistically significant decrease in plasma progesterone, estradiol, and prolactin on GD 17; these levels were not determined in the rats exposed to 100 μg/m^3^ (Archibong et al., 2002). Plasma prolactin is an indirect measure of the activity of decidual luteotropin, a prolactin-like hormone whose activity is necessary for luteal maintenance during pregnancy in rats. Control levels of prolactin increased from GD 15 to 17, but this increase did not occur in the rats exposed to 75 μg/m^3^. Although the progesterone concentration at 75 μg/m^3^ was significantly lower than in controls on GD 17, the authors thought that the circulating levels should have been sufficient to maintain pregnancy; thus, the increased loss of fetuses was thought to be caused by the lower prolactin levels rather than progesterone deficiency. The reduced circulating levels of progesterone and estradiol-17β among benzo[a]pyrene-treated rats were thought to be a result of limited decidual luteotropic support for the corpora lutea. The authors proposed the following mechanism for the effects of benzo[a]pyrene on fertility: benzo[a]pyrene or its metabolites decreased prolactin and decidual luteotropin levels, compromising the luteotropic support for the corpora lutea and thereby decreasing the plasma levels of progesterone and estradiol-17β. The low estradiol-17β may decrease uterine levels of progesterone receptors, thereby resulting in fetal mortality. Based on biologically and statistically significant decreases in pups/litter and percent fetal survival/per litter, the LOAEL was 25 μg/m^3^; no NOAEL was identified.

### 6.2.2 Alternative Inhalation Noncancer Assessment Using the Hazard Index Method for the Aromatic High Carbon Range Fraction

If the available analytical chemistry data quantify the concentrations of 1,1-biphenyl, naphthalene, BaP, or BeP in the air separately from the remainder of the aromatic high carbon range fraction, it is recommended that HQs for the individual chemicals with analytical data be calculated and an HI for the mixture be developed using the calculated HQs.

For subchronic inhalation exposures, the subchronic p-RfC for 1,1-biphenyl (0.004 mg/m^3^), the p-RfC for BeP (2 × 10^−6^ mg/m^3^), and the chronic RfC for BaP (2 × 10^−6^ mg/m^3^) can be used as the denominator in the HQ equations; as discussed above, use of the chronic BaP value is appropriate because it is based on a developmental study. In this alternative approach, the chronic RfC for BaP (2 × 10^−6^ mg/m^3^) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually.

For chronic inhalation exposures, the chronic RfCs or p-RfCs as shown in Table 8 can be used in the denominator of the HQ equations. In this alternative approach, the chronic RfC for BaP (2 × 10^−6^ mg/m^3^) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually.

## 6.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

Table 9 summarizes the noncancer health reference values for indicator chemicals used when available analytical data and exposure estimates are limited to either air concentrations of, or oral exposure rates associated with, the whole fraction. When analytical results, air concentrations, or exposure rate measures for individual compounds with reference values are available, then the hazards associated with these compounds are assessed separately, using the HI approach and reference values reported in Tables 6, 7, and 8. The mass of those compounds is then subtracted from the total mass of the fraction, and the risks associated with the remaining mass are assessed using the values in Table 9.

Table 9 Summary of Noncancer Reference Estimates for Aromatic High Carbon Range (C10–C32, EC11–EC35) Fraction of TPHs

Toxicity Type (units); Indicator Chemical | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD | UFc | Reference
Subchronic p-RfD (mg/kg-d); Benzo[a]pyrene | Rat/M, F | Neuro-development | 3 × 10^−4^ | BMDL_1SD_ | 0.092 | 300 | Chen et al. (2012) as cited in U.S. EPA (2017a)
Chronic p-RfD (mg/kg-d); Benzo[a]pyrene | Rat/M, F | Neuro-development | 3 × 10^−4^ | BMDL_1SD_ | 0.092 | 300 | Chen et al. (2012) as cited in U.S. EPA (2017a)
Subchronic p-RfC (mg/m^3^) Benzo[a]pyrene | Rat/M, F | Decreased embryo/fetal survival | 2 × 10^−6^ | LOAEL (HEC) | 0.0046 | 3,000 | Archibong et al. (2002) as cited in U.S. EPA (2017a)
Chronic p-RfC (mg/m^3^) Benzo[a]pyrene | Rat/M, F | Decreased embryo/fetal survival | 2 × 10^−6^ | LOAEL (HEC) | 0.0046 | 3,000 | Archibong et al. (2002) as cited in U.S. EPA (2017a)

BMDL_1SD_ = lower confidence limit on benchmark dose using benchmark response of 1 standard deviation change from control mean; C = carbon; EC = equivalent carbon; F = female(s); HEC = human equivalent concentration; M = male(s); POD = point of departure; p-RfC = provisional inhalation reference concentration; p-RfD = provisional oral reference dose; TPH = total petroleum hydrocarbon; UFc = composite uncertainty factor.