# 5 MECHANISTIC CONSIDERATIONS

Reactive oxidative metabolites of PAHs (e.g., benzo[a]pyrene diol epoxide [BPDE], 1,2-naphthoquinone) may bind covalently to proteins and nucleic acids, resulting in the cellular toxicity responsible for some noncancer health effects (IARC, 2010; ATSDR, 2005). Using naphthalene as an example, formation of cataracts following exposure is attributed to metabolism of naphthene dihydrodiol into 1,2-naphthoquinone in the lens of the eye (U.S. EPA, 1998). Additionally, GSH depletion and covalent protein binding have been implicated in the nasal and pulmonary toxicity produced by naphthalene due to formation of epoxide intermediates, naphthoquinones, and free radical reactive intermediates (U.S. EPA, 1998). GSH depletion is also associated with oxidative stress and the formation of reactive oxygen species. Oxidative stress has been suggested as a possible mechanism for several health effects of PAHs, including developmental and neurodevelopmental effects, male and female reproductive effects, immunotoxicity, and neurotoxicity (Agarwal et al., 2017; U.S. EPA, 2017a; Crepeaux et al., 2012; Suresh et al., 2009). PAH binding to, and activation of, the aryl hydrocarbon receptor has been shown to affect cellular growth and differentiation and has been postulated as a possible mechanism for the developmental, neurodevelopmental, immunotoxic, and neurotoxic effects of PAHs (U.S. EPA, 2017a). Studies provide support for several other PAH mechanisms, including deoxyribonucleic acid (DNA) damage of somatic and/or germ cell nucleic acids, stimulation of apoptosis, altered neurotransmitter levels, and changes in the balance of reproductive hormones (U.S. EPA, 2017a).

The urinary bladder toxicity observed in rats following exposure to 1,1-biphenyl is believed to be related to the formation of calculi (U.S. EPA, 2013). The liver toxicity of 1,1-biphenyl may be related to activation of peroxisome proliferation-activated receptors (PPARs), and the reduction in body weight may be a result of an inhibition of cellular respiration (U.S. EPA, 2013).

Formation of a γ-diketone metabolite (1,2,4-triacetylbenzene) is the proposed mechanism for peripheral neuropathy associated with exposure to 1,2,4-triethylbenzene (Tshala-Katumbay et al., 2006). While formation of 1,2,4-triactylbenzene has not been demonstrated, it is expected based on ortho arrangement of ethyl moieties (Tshala-Katumbay et al., 2006; Gagnaire et al., 1993). There are well-established data indicating that γ-diketone metabolites of 1,2-diethylbenzene and n-hexane (1,2-diacetylbenzene and 2,5-hexanedione, respectively) are associated with peripheral neuropathy (Mckee et al., 2015; OECD, 2007; U.S. EPA, 2005). In support of a role for γ-diketone metabolites in peripheral neuropathy, peripheral nerve damage is not observed following oral exposure to the isomer, 1,3,5-triethylbenzene, which does not have the potential to form a γ-diketone metabolite due to meta arrangement of ethyl moieties (Tshala-Katumbay et al., 2006; Gagnaire et al., 1993).