# 4 TOXICOKINETIC CONSIDERATIONS

The toxicokinetic properties of PAHs have been extensively reviewed (U.S. EPA, 2017a; IARC, 2010; ATSDR, 2005). In general, these compounds are well absorbed following inhalation, oral, and dermal exposure. The lipophilicity of PAHs facilitates absorption; however, compounds with lower molecular weight (i.e., two or three rings vs. five or six rings) are more rapidly and extensively absorbed (IARC, 2010). PAHs are widely distributed with some accumulation in adipose tissues. Oxidative metabolism by cytochrome P450 (CYP450) isozymes occurs rapidly, and is followed by conjugation with sulfate, glutathione (GSH), or glucuronic acid and excretion in urine and feces. Oxidative metabolites of PAHs include epoxides, phenols, dihydrodiols, phenol dihydrodiols, dihydrodiol epoxides, quinones, and tetrols.

1,1-Biphenyl is also rapidly and readily absorbed following oral exposure (U.S. EPA, 2013). Animal studies suggest a potential for absorption by inhalation as 1,1-biphenyl dust or vapors; however, the rate and extent of absorption following inhalation are not known (U.S. EPA, 2013). Absorption by the dermal route is also suggested, although data are limited to an in vitro study of percutaneous absorption (U.S. EPA, 2013). 1,1-Biphenyl is widely distributed in tissues with no indication of preferential accumulation or storage (U.S. EPA, 2013). It is rapidly metabolized by CYP450 isozymes to hydroxylated metabolites, which are conjugated with sulphate or glucuronic acid. 1,1-Biphenyl is rapidly eliminated from the body, primarily as conjugated hydroxylated metabolites in the urine.

1,2,4-Triethylbenzene is expected to form a γ-diketone metabolite (1,2,4-triacetyl-benzene) due to the ortho position of the ethyl moieties on the benzene ring (Tshala-Katumbay et al., 2006; Gagnaire et al., 1993). Its isomer, 1,3,5-triethylbenzene, is not expected to form a γ-diketone due to the meta position of the ethyl moieties.