# 3 REVIEW OF POTENTIALLY RELEVANT DATA (NONCANCER)

Compound-specific IRIS and PPRTV assessment documents, supplemented by the literature search findings for additional chemicals that met the structural criteria (described above) and review articles (Mckee et al., 2015; Baxter and Warshawsky, 2012; OECD, 2012; ATSDR, 2005) were assessed to evaluate the available noncancer toxicity data for compounds in the aromatic high carbon range fraction. Critical effects identified with existing toxicity values include developmental effects (neurodevelopmental changes, fetal skeletal anomalies), respiratory effects (pulmonary alveolar proteinosis), increased liver weight, decreased red blood cells (RBCs), renal effects (nephropathy, decreased kidney weights, renal papillary mineralization), clinical signs of neurotoxicity, and decreased body weight. Additional potential targets identified based on literature searches include the adult and developing reproductive system and the gastrointestinal (GI) system. Table 5 presents an overview of the human and animal data available to evaluate these primary toxicological endpoints for each aromatic high carbon range fraction compound and three relevant mixtures. As Table 5 shows, human data and inhalation data for animals are scarce. Animal oral data to assess consistency in effects across members of the fraction are widely available for body-weight effects and moderate for other endpoints. Chronic systemic toxicity information is lacking for all but five members of the fraction: naphthalene and 1,1-biphenyl have been tested in comprehensive 2-year systemic toxicity studies in animals (inhalation and oral, respectively); 1- and 2-methylnaphthalene have been evaluated in comprehensive 81-week oral studies; and BaP was evaluated in a 2-year cancer bioassay with limited reporting of nonneoplastic findings.

Table 5 Overview of Human and Animal Data Availability for Evidence Integration^a^

CASRN | Name | Rings | C | EC | Body Weight | Hematological | Neurological | Hepatic | Renal/Bladder | Respiratory | Gastrointestinal | Reproductive | Developmental
91-20-3 | Naphthalene | 2 | 10 | 11.57 | O, I | H, O, I | O, I | O, I | O, I | O, I | O, I | O, I | O
877-44-1 | 1,2,4-Triethylbenzene | 1 | 12 | 11.57 | O | | O
102-25-0 | 1,3,5-Triethylbenzene | 1 | 12 | 11.62 | O | | O
91-57-6 | 2-Methylnaphthalene | 2 | 11 | 12.72 | O, I | O, I | O, I | O, I | O, I | O, I | I | O, I
90-12-0 | 1-Methylnaphthalene | 2 | 11 | 12.77 | O | O | O | O | O | O | | O
92-52-4 | 1,1-Biphenyl | 2 | 12 | 13.45 | O, I | O | H | H, O, I | O, I | O, I | O | O | O
83-32-9 | Acenaphthene | 2 | 12 | 14.76 | O | O | O | O | O | O | O | O
86-73-7 | Fluorene | 2 | 13 | 15.68 | O | O | O | O | O | O | O | O
85-01-8 | Phenanthrene | 3 | 14 | 18.37 | O
120-12-7 | Anthracene | 3 | 14 | 18.43 | O | O | O | O | O | O | O | O
205-12-9 | Benzo[c]fluorene | 3 | 17 | 21.45 | O | | | | | | O
129-00-0 | Pyrene | 4 | 16 | 22.45 | O | O | O | O | O | O | O | O
206-44-0 | Fluoranthene | 3 | 16 | 21.11 | O | O | O | O | O | O | O | O
205-99-2 | Benzo[b]fluoranthene | 4 | 20 | 25.04 | O | | | | | | | | O
50-32-8 | Benzo[a]pyrene | 4 | 20 | 29.95 | O, I | O | H, O | O | O | O | O | H, O, I | H, O, I
192-97-2 | Benzo[e]pyrene ^b^ | 4 | 20 | 27.80 | | | | O
191-30-0 | Dibenzo[def,p]chrysene | 6 | 24 | 33.69 | | | | | | | | | O
NA | 16-PAH mixture | 2–6 | 10–22 | 11.57–32.62 | | | | | | | | | O
NA | 9-PAH mixture | 4–6 | 16–22 | 22.45–32.62 | | | | | | | | | I
NA | 21-PAH mixture | 1–6 | 9–22 | 11.57–32.62 | O | | | | | | O

a Includes human and animal studies meeting inclusion criteria. Bolded compounds have at least one oral or inhalation noncancer toxicity value available (see Table 4).

b The PPRTV assessment for benzo[e]pyrene (U.S. EPA, 2021b) discusses hepatotoxicity studies as well as immunotoxicity, cardiovascular toxicity, and retinol cell toxicity studies; however, as a result of the limitations of the available oral and inhalation toxicity data for benzo[e]pyrene, the U.S. EPA did not directly derive toxicity values. Instead, screening values were derived in Appendix A of the U.S. EPA PPRTV assessment document, using an alternative analogue approach.

EC = equivalent carbon; H = human data; I = animal inhalation studies; NA = not applicable; O = animal oral studies; PAH = polycyclic aromatic hydrocarbons; PPRTV = Provisional Peer-Reviewed Toxicity Value; U.S. EPA = U.S. Environmental Protection Agency.

To evaluate consistency in endpoint-specific potencies across members of the fraction, the dose-response data from animal studies that met selection criteria were extracted (from IRIS, PPRTV assessment documents, and primary and secondary literature sources) and presented in exposure-response arrays by health outcome and exposure route (see Appendix C). Based on review of the available data presented in Appendix C, there is evidence to suggest consistency in body-weight changes, neurological effects, hepatic effects, and hematological effects of some aromatic high carbon range fraction members, but not enough to indicate consistency across the entire fraction. Available data indicate that the kidney and bladder are particularly susceptible to 1,1-biphenyl toxicity, with data from other compounds generally showing increased incidence of age-related nephropathy. There is little evidence to indicate respiratory tract effects following oral exposure for compounds other than 1- and 2-methylnaphthalene (for which pulmonary findings are confounded by inhalation exposure via volatilization from feedstock), although there is limited evidence to suggest consistency in respiratory effects following inhalation exposure across compounds with lower carbon numbers (no data for fraction members with higher carbon numbers; C13−35). The available data are not adequate to provide confidence in an assessment of the consistency in effects for GI tract, reproductive toxicity, or developmental toxicity endpoints (including neurodevelopment and reproductive development).