# 2 SUMMARY OF TOXICITY AND DOSE-RESPONSE ASSESSMENT APPROACH FOR NONCANCER EFFECTS

The indicator chemical approach and the HI approach are used for hazard assessment for the aromatic high carbon range fraction. Both approaches require toxicity and dose-response assessment data. These data depend upon the identification of component chemicals and mixtures with existing toxicity values, and the identification of hazard information. The approach for identifying this information is outlined here and described in additional detail in subsequent sections. Mixtures and compounds that met structural criteria (see definition of the fraction in Section 1.1) and had available toxicity values from designated sources were identified, as was relevant hazard information.

Literature searches were performed for the mixtures and compounds with toxicity values and for other mixtures and compounds that are relevant to the fraction. These literature searches were conducted in February 2018 and date-limited to assessments and literature published after 2007^2^. These literature searches were updated most recently in August 2021. The literature searches were designed for several purposes. First, the literature searches were to determine whether new information suggested that toxicity values for mixtures or compounds relevant to the fraction (see definition of the fraction, in Section 1.1) should be updated from those identified in the U.S. EPA (2009b) PPRTV assessment for mixtures of aliphatic and aromatic hydrocarbons. Second, the literature searches were to determine whether new noncancer toxicity values or data on other mixtures or compounds meeting the structural criteria of the fraction might alter the overall understanding of the toxicity of the fraction. Third, a search of recent comprehensive reviews was conducted on the toxicity of petroleum components or classes of compounds relevant to the fraction, as well as Organisation for Economic Co-operation and Development (OECD) Screening Information Data Set (SIDS) assessments^3^ and the Petroleum High Production Volume (HPV) Testing Group website, to identify other mixtures or compounds with toxicity data that may inform hazard identification for the fraction. Toxicity data criteria included human studies of any duration by oral, inhalation, and dermal exposure, and animal studies of oral or inhalation exposure lasting at least 28 days (or any duration of gestational exposure). Mixture toxicity data were considered relevant only if the mixture composition under study was quantitatively defined to enable assessment of relevance to the fraction. Figure 2 shows a schematic depiction of the process, and further detail is provided below.

Figure 2 Selection of Compounds and Mixtures for Aromatic High Carbon Range Fraction Hazard Identification and Noncancer Dose-Response Assessment

ATSDR = Agency for Toxic Substances and Disease Registry; C = carbon; EC = equivalent carbon; HPV = High Production Volume: IRIS = Integrated Risk Information System; OECD = Organisation for Economic Co-operation and Development; PPRTV = Provisional Peer-Reviewed Toxicity Value; RfC = reference concentration; RfD = reference dose; SIDS = Screening Information Data Set.

Compounds and mixtures relevant to the aromatic high carbon range fraction with available toxicity values or data were identified. Table 3 lists individual compounds and mixtures and links them to their corresponding identification source during the literature search process. Table 3 also indicates compounds with available toxicity values, or in the absence of toxicity values, available toxicity data.

## 2.1 IDENTIFICATION OF RELEVANT MIXTURES AND COMPOUNDS WITH NONCANCER TOXICITY VALUES

In Step 1 of the assessment (see Figure 2), the U.S. EPA identified constituents of the fraction that have existing toxicity values from any of the sources considered for the U.S. EPA (2009b) PPRTV assessment for Complex Mixtures of Aliphatic and Aromatic Hydrocarbons; these included assessments on the Integrated Risk Information System [IRIS], PPRTV assessments, Agency for Toxic Substances and Disease Registry [ATSDR] Minimal Risk Levels [MRLs], Massachusetts Department of Environmental Protection [MassDEP], the Total Petroleum Hydrocarbon Criteria Working Group [TPHCWG], and Health Effects Assessment Summary Tables [HEAST]). Of these sources, only IRIS, PPRTVs, and ATSDR MRLs have been updated since 2009, so only these sources were consulted for updated toxicity values. Beginning with an initial list of 41 chemicals considered relevant to the fraction [see the full list in Table 3 as well as a description of the approach and results in Wang et al. (2012)], the IRIS, PPRTVs, and ATSDR MRLs were reviewed for noncancer toxicity values. At least one subchronic or chronic oral reference value or subchronic or chronic inhalation reference value was available for 11 chemicals (acenaphthene, anthracene, BaP, benzo[e]pyrene [BeP], 1,1-biphenyl, fluoranthene, fluorene, 1-methylnaphthalene, 2-methylnaphthalene, naphthalene, and pyrene). Table 4 shows the noncancer toxicity values available for the 11 relevant compounds.

Table 3 Chemicals and Mixtures Identified in Literature Searches

CASRN | Chemical Name | Literature Search Identification Source | PubMed Searches Performed | Toxicity Values Identified | Toxicity Data Identified
92-52-4 | 1,1-Biphenyl | Initial list of 41^a^ | X | X
26137-53-1 | 1,2,3-Trimethyl-4-propenyl-naphthalene | Updated PPRTV, IRIS, and ATSDR MRL databases^b^ | X
877-44-1 | 1,2,4-Triethylbenzene | Recent reviews of petroleum toxicity^c,^ ^d^ | | | X
527-53-7 | 1,2,3,5-Tetramethylbenzene | Initial list of 41^a^ | X
575-41-7 | 1,3-Dimethylnaphthalene | Initial list of 41^a^ | X
102-25-0 | 1,3,5-Triethylbenzene | Recent reviews of petroleum toxicity^c,^ ^d^ | | | X
202-94-8 | 11H-Benzo[b,c]aceanthrylene | Initial list of 41^a^ | X
90-12-0 | 1-Methylnaphthalene | Initial list of 41^a^ | X | X
Various | 16-PAH mixture | Informal PubMed searches^e,^ ^f^ | X | | X
243-17-4 | 2,3-Benzofluorene | Updated PPRTV, IRIS, and ATSDR MRL databases^b^ | X
581-42-0 | 2,6-Dimethylnaphthalene | Initial list of 41^a^ | X
91-57-6 | 2-Methylnaphthalene | Initial list of 41^a^ | X | X
Various | 21-PAH mixture^g^ | Recent reviews of petroleum toxicity^c,^ ^h^ | | | X
202-98-2 | 4H-Cyclopenta[d,e,f]chrysene | Initial list of 41^a^ | X
Various | 9-PAH mixture | Informal PubMed searches^e,^ ^i^ | X | | X
83-32-9 | Acenaphthene | Initial list of 41^a^ | X | X
208-96-8 | Acenaphthylene | Updated PPRTV, IRIS, and ATSDR MRL databases^b^ | X
191-26-4 | Anthanthrene | Initial list of 41^a^ | X
120-12-7 | Anthracene | Initial list of 41^a^ | X | X
56-55-3 | Benzo[a]anthracene | Initial list of 41^a^ | X
50-32-8 | Benzo[a]pyrene | Initial list of 41^a^; oral and inhalation toxicity values^j^ | | X
205-99-2 | Benzo[b]fluoranthene | Initial list of 41^a^ | X | | X
205-12-9 | Benzo[c]fluorene | Recent reviews of petroleum toxicity^c,^ ^h^ | | | X
192-97-2 | Benzo[e]pyrene | Updated PPRTV, IRIS, and ATSDR MRL databases^b^; oral and inhalation toxicity values^j^ | | X
191-24-2 | Benzo[ghi]perylene | Initial list of 41^a^ | X
207-08-9 | Benzo[k]fluoranthene | Initial list of 41^a^ | X
199-54-2 | Benzo[e]aceanthrylene | Initial list of 41^a^ | X
202-33-5 | Benzo[j]aceanthrylene | Initial list of 41^a^ | X
205-82-3 | Benzo[j]fluoranthene | Initial list of 41^a^ | X
211-91-6 | Benzo[l]aceanthrylene | Initial list of 41^a^ | X
218-01-9 | Chrysene | Initial list of 41^a^ | X
191-07-1 | Coronene | Updated PPRTV, IRIS, and ATSDR MRL databases^b^ | X
27208-37-3 | Cyclopenta[c,d]pyrene | Initial list of 41^a^ | X
191-30-0 | Dibenzo[a,l]pyrene | Initial list of 41^a^ | X | | X
215-58-7 | Dibenzo[a,c]anthracene | Initial list of 41^a^ | X
5385-75-1 | Dibenzo[a,e]fluoranthene | Initial list of 41^a^ | X
192-65-4 | Dibenzo[a,e]pyrene | Initial list of 41^a^ | X
53-70-3 | Dibenzo[a,h]anthracene | Initial list of 41^a^ | X
189-64-0 | Dibenzo[a,h]pyrene | Initial list of 41^a^ | X
189-55-9 | Dibenzo[a,i]pyrene | Initial list of 41^a^ | X
206-44-0 | Fluoranthene | Initial list of 41^a^ | X | X
86-73-7 | Fluorene | Initial list of 41^a^ | X | X
193-39-5 | Indeno[1,2,3-c,d]pyrene | Initial list of 41^a^ | X
91-20-3 | Naphthalene | Initial list of 41^a^; oral and inhalation toxicity values^j^ | | X
193-09-9 | Naphtho[2,3-e]pyrene | Initial list of 41^a^ | X
1078-71-3 | n-Heptylbenzene | Initial list of 41^a^ | X
1077-16-3 | n-Hexylbenzene | Initial list of 41^a^ | X
2189-60-8 | n-Octylbenzene | Initial list of 41^a^ | X
538-68-1 | n-Pentylbenzene | Initial list of 41^a^ | X
198-55-0 | Perylene | Updated PPRTV, IRIS, and ATSDR MRL databases^b^ | X
85-01-8 | Phenanthrene | Initial list of 41^a^ | X | | X
827-52-1 | Phenylcyclohexane | Initial list of 41^a^ | X
129-00-0 | Pyrene | Initial list of 41^a^ | X | X

a The U.S. EPA developed the initial list of 41 chemicals relevant to the aromatic medium carbon range. The list included all individual hydrocarbons considered previously by the U.S. EPA’s STSC in the evaluation of hydrocarbons, as well as all those with toxicity data reviewed by the MassDEP (MassDEP, 2003) or the TPHCWG (Edwards et al., 1997).

b During review of the updated IRIS, PPRTV, and ATSDR MRL databases, these compounds were identified in the PPRTV database as meeting structural criteria for inclusion and having toxicity assessments.

c These compounds/mixtures were identified in Mckee et al. (2015) and Baxter and Warshawsky (2012), reviews of petroleum toxicity.

d Toxicity data for these compounds were found in Tshala-Katumbay et al. (2006).

e These mixtures were identified in PubMed searches using the terms “‘polycyclic aromatic hydrocarbons’ AND mixture AND (rat or mouse or hamster or rabbit).”

f Toxicity data for this mixture were found in Crepeaux et al. (2014); (Crepeaux et al., 2013, 2012).

g The 21-PAH mixture includes 1- and 2-methylnaphthalene, which are substituted PAHs (subPAHs). For simplicity, it is referred to as a 21-PAH mixture rather than a 19-PAH and 2-subPAH mixture.

h Toxicity data for these compounds/mixtures were found in Weyand et al. (2004).

i Toxicity data for this mixture were found in Yan et al. (2014) and Chu et al. (2013).

j Because these compounds had IRIS, PPRTV, or ATSDR toxicity values for both oral and inhalation routes, no additional literature searches were performed.

ATSDR = Agency for Toxic Substances and Disease Registry; IRIS = Integrated Risk Information System; MassDEP = Massachusetts Department of Environmental Protection; MRL = minimal risk level; PAH = polycyclic aromatic hydrocarbon; PPRTV = Provisional Peer-Reviewed Toxicity Value; STSC = Superfund Technical Support Center; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group; U.S. EPA = U.S. Environmental Protection Agency.

Table 4 Summary of Available Noncancer Toxicity Values for Constituents of Aromatic High Carbon Range (C10–C32, EC11–EC35) Fraction^a,^ ^b^

CASRN | Name | C | EC | Oral Reference Dose (mg/kg-d) | | Inhalation Reference Concentration (mg/m^3^)
CASRN | Name | C | EC | Subchronic | Chronic | Subchronic | Chronic
91-20-3 | Naphthalene | 10 | 11.57 | 0.6 (ATSDR) | 0.02 (IRIS) | – | 0.003 (IRIS)
91-57-6 | 2-Methyl-naphthalene | 11 | 12.72 | 0.004 (PPRTV) | 0.004 (IRIS) | – | –
90-12-0 | 1-Methyl-naphthalene | 11 | 12.77 | – | 0.007^*^ (PPRTV) | – | –
92-52-4 | 1,1-Biphenyl | 12 | 13.45 | 0.1 (PPRTV) | 0.5 (IRIS) | 0.004^*^ (PPRTV) | 0.0004^*^ (PPRTV)
83-32-9 | Acenaphthene | 12 | 14.76 | 0.2 (PPRTV) | 0.06 (IRIS) | – | –
86-73-7 | Fluorene | 13 | 15.68 | 0.4 (ATSDR) | 0.04 (IRIS) | – | –
120-12-7 | Anthracene | 14 | 18.43 | 1 (PPRTV) | 0.3 (IRIS) | – | –
129-00-0 | Pyrene | 16 | 22.45 | 0.3 (PPRTV) | 0.03 (IRIS) | – | –
206-44-0 | Fluoranthene | 16 | 21.11 | 0.1 (PPRTV) | 0.04 (IRIS) | – | –
192-97-2 | Benzo[e]pyrene^c^ | 20 | 27.80 | 0.00009^*^ (PPRTV) | 0.00009^*^ (PPRTV) | 0.000002^*^ (PPRTV) | 0.000002^*^ (PPRTV)
50-32-8 | Benzo[a]pyrene | 20 | 29.95 | 0.0003^d^ (IRIS) | 0.0003 (IRIS) | 0.000002^d^ (IRIS) | 0.000002 (IRIS)

a Toxicity values shown were selected from the following sources in order of preference: IRIS, PPRTVs, ATSDR, HEAST, MassDEP, or TPHCWG.

b Appendix B of the TPH mixture PPRTV (U.S. EPA, 2022, 2021c) assessment provides a table containing all chemicals with toxicity values listed in any of the individual TPH fractions. The table lists the chemical name used in PPRTV assessments and its corresponding acronym, common synonyms listed in U.S. EPA’s CompTox Chemicals Dashboard, CASRN, structure, and molecular weight.

c The screening subchronic and chronic p-RfDs and the screening subchronic and chronic p-RfCs are derived using an alternative analogue approach in the PPRTV assessment (U.S. EPA, 2021b).

d The chronic RfD and RfC values for benzo[a]pyrene are based on a developmental exposure; therefore, they are also applicable to subchronic exposures and are listed here.

* Screening toxicity value.

ATSDR = Agency for Toxic Substances and Disease Registry; C = carbon; EC = equivalent carbon; HEAST = Health Effects Assessment Summary Tables; IRIS = Integrated Risk Information System; MassDEP = Massachusetts Department of Environmental Protection; PPRTV = Provisional Peer-Reviewed Toxicity Value; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; TPH = total petroleum hydrocarbon; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group; U.S. EPA = U.S. Environmental Protection Agency.

In Step 2 (see Figure 2), other assessments in the IRIS, PPRTV, and ATSDR databases were reviewed to determine whether there were any other compounds or mixtures not in the initial list that met the structural criteria for inclusion (C10−C32 and EC11−EC35 aromatics). Searches of the IRIS and ATSDR databases did not identify any additional compounds, but review of the PPRTV database identified five additional compounds that met structural criteria for inclusion and had toxicity assessments: acenaphthylene, 2,3-benzofluorene, coronene, perylene, and 1,2,3-trimethyl-4-propenylnaphthalene. None of these PPRTV assessments included toxicity value derivations or any relevant toxicity data. The U.S. EPA derived a toxicity value for BeP, a compound that met structural criteria for inclusion in the fraction.

## 2.2 IDENTIFICATION OF OTHER RELEVANT TOXICITY DATA

Among the 47 compounds outlined above (41 chemicals in the U.S. EPA’s initial list plus 6 chemicals [acenaphthylene, BeP, 2,3-benzofluorene, coronene, perylene, and 1,2,3-trimethyl-4-propynylnaphthalene] found during the search of PPRTV database), there were 11 compounds with noncancer toxicity values (see Table 4). Four of these compounds (BaP, BeP, naphthalene, and 1,1-biphenyl) had IRIS or PPRTV toxicity values for both oral and inhalation routes; no additional literature searches were performed for these compounds. For the remaining 44 members, literature searches in PubMed were conducted in Step 3 (see Figure 2) to identify any new studies that fill data gaps. The literature searches were date-limited to studies published from 2007 forward in order to capture studies that were published since the searches performed for the 2009 PPRTV assessment for TPH mixtures (U.S. EPA, 2009b). This search was updated most recently in August 2021. A summary of the literature search strategy is provided in Appendix A. As detailed in Appendix A, studies considered relevant to hazard identification included animal studies using inhalation or oral exposure routes, in which exposures continued for at least 28 days (or any duration of gestational exposure), at least one health outcome was assessed, and an untreated or vehicle control group was included. Human studies of any duration in which exposure was known or presumed to be through oral, inhalation, or dermal routes and at least one health outcome was assessed were considered relevant.

The update literature search identified 11 epidemiological studies of noncancer effects in humans exposed to undefined PAH mixtures: Agarwal et al. (2017); Alhamdow et al. (2017); Mortamais et al. (2017); Sram et al. (2017); Yang et al. (2017); Yin et al. (2017); Ranjbar et al. (2015); Clark et al. (2012); Wang et al. (2016); Xu et al. (2010); and Suresh et al. (2009). These studies were primarily focused on cardiovascular, immune, and neurological or neurodevelopmental outcomes. New animal studies identified in the searches and considered relevant include an oral developmental study of benzo[b]fluoranthene (Kim et al., 2011), a 28-day oral neurobehavioral study of fluorene (Peiffer et al., 2016), and a 28-day inhalation study of 2-methylnaphthalene (Swiercz et al., 2011).

The literature searches also identified oral studies of dibenzo[def,p]chrysene (also known as dibenzo[a,l]pyrene) (Fish and Benninghoff, 2017a, b; Madeen et al., 2016; Shorey et al., 2013; Shorey et al., 2012; Castro et al., 2009; Castro et al., 2008c; Castro et al., 2008a; Castro et al., 2008b). Dibenzo[def,p]chrysene was not reported as a constituent of petroleum products in Gustafson et al. (1997). However, because only the 16 PAHs with noncancer or cancer toxicity values have historically been measured in most environmental media (U.S. EPA, 2021d; Keith, 2015), the lack of detections reported by Gustafson et al. (1997) may not reflect the actual composition of the mixture. In addition, detection limits at the time may not have been low enough to reveal very low concentrations of PAHs such as dibenzo[def,p]chrysene. For example, NLM (2017d) reported that dibenzo[def,p]chrysene “occurs as a result of incomplete burning of fossil fuels, wood, diesel oils and gasoline fuels.” Therefore, it was considered to be relevant to petroleum contamination.

In Step 4 (see Figure 2), to determine whether additional relevant compounds or mixtures had been tested for repeat-dose and/or reproductive/developmental toxicity since 2007, recent reviews of petroleum toxicity (Mckee et al., 2015; Baxter and Warshawsky, 2012), an OECD (2012) SIDS dossier, and the Petroleum HPV Testing Group website were searched.

Searches of the Mckee et al. (2015) and Baxter and Warshawsky (2012) reviews identified three additional compounds with relevant (oral or inhalation, at least 28 days of exposure or any duration during development) animal toxicity data: 1,2,4-triethylbenzene, 1,3,5-triethylbenzene, and benzo[c]fluorene. Both of the triethylbenzenes were tested for neurotoxicity in a study of mice exposed orally for 5 weeks (Tshala-Katumbay et al., 2006). Benzo[c]fluorene, as well as a mixture of 21 PAHs, was tested for oral carcinogenicity in mice (Weyand et al., 2004); a few noncancer endpoints were reported. The 21-PAH mixture included one compound that was outside the carbon range (indan, C9); however, it was present at <1% in the mixture. The mixture composition is shown in Appendix B (see Table B-1). A subchronic oral study (Dalbey et al., 2014) of heavy paraffinic distillate aromatic extract in rats was located on the Petroleum HPV Testing Group website. However, this mixture included compounds outside the fraction range (as high as C50) and contained approximately 15% aliphatic compounds. Thus, it did not meet structural requirements for the aromatic high carbon range fraction and was not considered further.

Finally, in Step 5 (see Figure 2), PubMed searches using the terms “polycyclic aromatic hydrocarbons’ AND mixture AND (rat or mouse or hamster or rabbit)” were performed to determine whether any oral or inhalation animal studies of mixtures that met inclusion criteria were available. Mixtures considered relevant to the fraction met the following criteria (see Figure 2):

1. at least 90% of the mixture consisted of identified compounds within the C10−C32 and/or EC11−EC35 ranges, and highly toxic lower aromatic carbons (e.g., benzene) were not present.
2. 99% of the mixture consisted of aromatic compounds (≤1% aliphatic).
3. the mixture had been tested in animals in at least one repeat-dose (≥28 days) or reproductive/developmental toxicity study using inhalation or oral exposure routes and included an untreated or vehicle control group.
4. human mixture studies of any duration by oral, inhalation, and dermal exposure, and animal studies of oral or inhalation exposure lasting at least 28 days (or any duration of gestational exposure).

In addition, mixture studies were considered relevant only if the composition of the test material was clearly defined.

The PubMed searches identified three neurodevelopmental studies of oral exposure to a 16-PAH mixture (Crepeaux et al., 2014, 2013, 2012), and two studies of inhalation exposure to a nebulized 9-PAH mixture during gestation or lactation, examining adiposity (Yan et al., 2014) and immune (Chu et al., 2013) endpoints in offspring. Compositions of the 16- and 9-PAH mixtures are shown in Appendix B (see Tables B-2 and B-3, respectively).

In summary, relevant toxicity data for compounds or mixtures that lack toxicity values were identified from reviews or literature searches for five compounds (benzo[b]fluoranthene, benzo[c]fluorene, dibenzo[def,p]chrysene, 1,2,4-triethylbenzene, and 1,3,5-triethylbenzene) and three defined mixtures (21-, 16-, and 9-PAH mixtures). In addition, limited toxicity data that were not sufficient to derive a toxicity value are available in the PPRTV assessment for phenanthrene (U.S. EPA, 2009c), bringing the total number of compounds with available toxicity data but no existing toxicity values to six.

## 2.3 METHODS FOR INDICATOR CHEMICAL SELECTION

Only compounds or mixtures with at least one U.S. EPA or ATSDR toxicity value (see Table 4) were considered for use as potential indicator chemicals for derivation of the fraction-specific toxicity values, although toxicity data for other compounds were used for hazard identification and to assess consistency in effects and potency across the components of the fraction. The method for selecting indicator chemicals was adapted from the 2009 complex TPH mixtures document (U.S. EPA, 2009b). First, mixtures were preferred over individual compounds, provided that the mixture exhibited in vivo toxic effects and potency similar to those exhibited by the individual fraction components.

If suitable mixture data were lacking, but available component data indicated similar toxicity targets and potency, a representative compound exhibiting in vivo toxic effects and potency similar to those exhibited by other compounds in the fraction was chosen. In the event that components of the fraction varied widely in toxic effects or potency, the toxicity value for the most toxic component was selected as an indicator chemical for the fraction. Finally, if toxicity values were available for many or most of the individual compounds in a fraction, and these compounds are typically monitored at a site of hydrocarbon contamination, then an indicator chemical would be considered. In the case of studies where the exposures or doses occurred during fetal development, chronic toxicity values were considered representative of both chronic and subchronic exposures and were used as the subchronic toxicity value of the indicator chemical if they included the most sensitive endpoint.

2 The literature searches were date-limited to studies published from 2007 forward in order to capture studies that were published since the searches performed for the 2009 PPRTV assessment for TPH mixtures (U.S. EPA, 2009b).

3 The OECD Existing Chemicals Database (https://hpvchemicals.oecd.org) was reviewed for C10−C13 aromatic solvents.