# 1 INTRODUCTION

This Provisional Peer-Reviewed Toxicity Value (PPRTV) assessment supports a fraction-based approach to risk assessment for mixtures of petroleum hydrocarbons (U.S. EPA, 2022, 2009b). In this approach, total petroleum hydrocarbon (TPH) fractions are defined based on expected transport in the environment and analytical methods used to quantify environmental contamination by TPH mixtures. TPH components were first classified into aromatics and aliphatics, and each of these two major fractions were further separated into low, medium, and high carbon range fractions. This PPRTV assessment describes the derivation of noncancer toxicity values for the aromatic high carbon range fraction of TPH. The toxicity values described herein are used in the assessment of Complex Mixtures of Petroleum Hydrocarbons that is intended to replace current approaches used at TPH-contaminated sites (U.S. EPA, 2022, 2009b).

In general, fraction-based approaches involve: (1) dividing a complex mixture into groups based on similarities in their chemical structures or chemical properties; (2) measuring the concentrations of these groups (or the components within the group) in environmental media or estimating the rates of human exposure (e.g., mg/kg-day) to these groups; (3) selecting an approach to characterize a dose-response relationship for the group; (4) combining the dose-response approach and the exposure estimates for all members of the group to estimate health risks from the group; and (5) estimating risks or hazards posed by exposure to the complex mixture using the risk characterization information from the individual groups [adapted from ATSDR (2018)].

## 1.1 DEFINITION OF THE AROMATIC HIGH CARBON RANGE FRACTION

The aromatic high carbon range fraction includes aromatic hydrocarbons with a carbon (C) range of C10−C32 (contains between 10 and 32 carbons, inclusive) and an equivalent carbon (EC)^1^ number index range of EC11−EC35 that occur in, or co-occur with, petroleum contamination. Hydrocarbons with a carbon number greater than C32 are not included in the aromatic high carbon range fraction due to limited bioavailability driving a lack of toxicity observed in in vivo studies, limited potential for transport via groundwater flow and via volatilization to the air, and incompatibility with existing standard analytical methods (Boogaard et al., 2017; Shell Global Solutions International et al., 2017; Gustafson et al., 1997). While the aromatic medium carbon range fraction also includes C10 compounds, the aromatic medium carbon range fraction is restricted to those compounds with EC9−EC < 11. For this reason, naphthalene (C10, EC11.57) is included in the aromatic high carbon range fraction. The EC index is equivalent to the retention time of the compound on a boiling-point gas chromatography (GC) column (nonpolar capillary column), normalized to the n-alkanes (NJ DEP, 2010). EC numbers are the physical characteristic that underpin analytical separation of petroleum components. EC numbers are useful because they are more closely related to environmental mobility than carbon number. For instance, two chemicals with similar carbon numbers but different structures (e.g., aliphatic vs. aromatic) could partition differently into environmental media and, ultimately, have different environmental fates. Grouping based on EC numbers provides a consistent basis for logically placing petroleum hydrocarbon compounds into fractions, because EC measures correlate with physicochemical properties such as water solubility, vapor pressure, Henry’s law constant, and soil adsorption coefficient (log Koc). Toxicological considerations also are a consideration when defining the aromatic high carbon range fraction. Substituted benzenes (C9−C10; contained within the aromatic medium carbon fraction) were grouped separately from polycyclic aromatic hydrocarbons (PAHs), naphthalenes, and 1,1-biphenyl (contained within the aromatic high carbon range fraction), which generally exhibit greater carcinogenicity and noncancer toxicity. Individual compounds in this fraction have a backbone consisting of one or more aromatic rings, which can be substituted with alkane, alkene, and other nonaromatic ring structures. Example compounds include 1,2,4-triethylbenzene, 2-methylnaphthalene, fluorene, and benzo[a]pyrene (BaP). Compounds with two to six fused unsubstituted aromatic rings without anything other than carbon or hydrogen in their composition are characterized as PAHs. The selection of relevant compounds and mixtures is described in Section 2 and Appendices A and B.

## 1.2 OVERVIEW OF PHYSICOCHEMICAL PROPERTIES AND ENVIRONMENTAL FATE

The systematic chemical names, synonyms [following guidance in NIST (2020b)], CASRNs, chemical abbreviations, chemical structures, and molecular weights for chemicals in this document are listed in Table 1 and in Appendix B of U.S. EPA (2022). The physicochemical properties for members of the aromatic high carbon range fraction that have noncancer toxicity values compiled from the CompTox Chemicals Dashboard (U.S. EPA, 2021a) are provided in Table 2. Section 2 details how the fraction members with toxicity values were identified. The representative chemicals identified are 1,1-biphenyl and eight PAHs, including naphthalene, and two methyl-substituted naphthalene compounds (CASRNs 91-57-6 and 90-12-0). These chemicals are all solids except for 1-methylnaphthalene (CASRN 90-12-0), which is a liquid at room temperature; they have moderate to low water solubility and vapor pressure. Members of this fraction are expected to have little to no mobility in soil based on measured K_oc_ data; however, the K_oc_ for naphthalene suggests potential mobility in some soil types. Volatilization of members of this fraction from water and moist soil will be moderate based upon the measured Henry’s law constant values for the representative compounds. Volatilization from dry soil surfaces will be low to moderate based upon the measured vapor pressure values. Measured aerobic and anaerobic biodegradation data are available for the representative compounds. Under aerobic conditions, the nine PAHs are expected to have slow removal by biodegradation in unacclimated systems and more rapid biodegradation in acclimated systems. Acclimation periods (days to months) have been observed prior to the onset of microbial degradation in tests using soil not previously exposed to PAHs. It is thought that this occurs because small population(s) of organisms capable of PAH degradation must attain sufficient densities before detectable PAH reduction is observed (Mihelcic and Luthy, 1988). 1,1-Biphenyl undergoes biodegradation more readily than the many PAHs, as demonstrated in a modified test where 1,1-biphenyl achieved 66% of its theoretical biochemical oxygen demand (BOD) after 14 days (compared to 0–2% after 28 days for naphthalene and acenaphthalene) (ECHA, 2019; OECD, 2009; CITI, 1992). Under anaerobic conditions, biodegradation is slow for all fraction members. Members of the aromatic high carbon range fraction do not contain hydrolysable functional groups; therefore, the rate of hydrolysis is expected to be negligible for all fraction members. In the atmosphere, the rate of photooxidation is expected to be moderate for fraction members. Many of the fraction members, except, for example, 1,1-biphenyl, contain chromophores that absorb light at wavelengths >290 nm, and are therefore expected to be susceptible to direct photolysis by sunlight (NLM, 2017a, b, c, e, f, g, 2015a, b, 2014, 2005). When the fraction members occur in the atmosphere in the particulate phase, they will be physically removed by wet and dry deposition.

Table 1 Synonyms and Abbreviations for Chemicals in this PPRTV Assessment^a^

Chemical (common synonyms^b^) | CASRN | Abbreviation | Structure | Molecular Weight (g/mol)
Naphthalene; (naphthalin) | 91-20-3 | NPT | Chemical symbol for Naphthalene | 128.174
2-Methylnaphthalene; (naphthalene, 2-methyl-) | 91-57-6 | 2MeNPT | Chemical symbol for Methylnaphthalene | 142.201
1-Methylnaphthalene; (naphthalene, 1-methyl-) | 90-12-0 | 1MeNPT | Chemical symbol for Methylnaphthalene | 142.201
1,1-Biphenyl; (biphenyl; 1,1′-biphenyl) | 92-52-4 | BH | Chemical symbol for Biphenyl | 154.212
Acenaphthene; (acenaphthylene, 1,2-dihydro-; 1,2-dihydroacenaphthylene; 1,8-ethylenenaphthalene) | 83-32-9 | ANL | Chemical symbol for Acenapthene | 154.212
Fluorene; (9H-fluorene; 2,3-benzidene; o-biphenylenemethane; diphenylenemethane; 2,2′-methylenebiphenyl; o-biphenylmethane) | 86-73-7 | FE | Chemical symbol for Fluorene | 166.223
Anthracene; (anthracin; paranaphthalene) | 120-12-7 | AC | Chemical symbol for Anthracene | 178.234
Pyrene; (benzo[def]phenanthrene; pyren) | 129-00-0 | Pyr | Chemical symbol for Pyrene | 202.256
Fluoranthene; (ClusterCarbon; idryl; benzo[jk]fluorene; 1,2-[1,8-naphthalenediyl]benzene; benz[a]acenaphthylene; 1,2-benzoacenaphyhylene) | 206-44-0 | FA | Chemical symbol for Fluoranthene | 202.256
Benzo[a]pyrene; (benzo[pqr]tetraphene; benzo[def]chrysene; 1,2-benzpyrene; 3,4-benzopyren; 4,5-benzpyrene; 6,7-benzopyrene) | 50-32-8 | BaP | Chemical symbol for Benzoapyrne | 252.316
Benzo[e]pyrene | 192-97-2 | BeP | Chemical symbol for Benzoepyrene | 252.316

a Only chemicals with toxicity values are listed.

b Synonyms are listed according to NIST (2020b) and include valid synonyms from U.S. EPA CompTox Chemicals Dashboard; accessed 03-30-2020; U.S. EPA (2021a).

PPRTV = Provisional Peer-Reviewed Toxicity Value; U.S. EPA = U.S. Environmental Protection Agency.

Table 2 Physicochemical Properties of Aromatic High Carbon Range Chemicals with Noncancer Toxicity Values^a^

Chemical | NPT | 2MeNPT | 1MeNPT | BH | ANL | FE | AC | Pyr | FA | BaP | BeP
Structure | Chemical symbol for NPT | Chemical symbol for 2MeNPT | Chemical symbol for 1MeNPT | Chemical symbol for BH | Chemical symbol for ANL | Chemical symbol for FE | Chemical symbol for AC | Chemical symbol for Pyr | Chemical symbol for FA | Chemical symbol for BaP | Chemical symbol for BeP
CASRN | 91-20-3 | 91-57-6 | 90-12-0 | 92-52-4 | 83-32-9 | 86-73-7 | 120-12-7 | 129-00-0 | 206-44-0 | 50-32-8 | 192-97-2
Molecular formula | C_10_H_8_ | C_11_H_10_ | C_11_H_10_ | C_12_H_10_ | C_12_H_10_ | C_13_H_10_ | C_14_H_10_ | C_16_H_10_ | C_16_H_10_ | C_20_H_12_ | C_20_H_12_
EC number^b^ | 11.57 | 12.72 | 12.77 | 13.45 | 14.76 | 15.68 | 18.43 | 22.45 | 21.11 | 29.95 | 27.80
Molecular weight (g/mol) | 128.174 | 142.201 | 142.201 | 154.212 | 154.212 | 166.223 | 178.234 | 202.256 | 202.256 | 252.316 | 252.316
Melting point (°C) | 80.3 | 33.7 | −3.10 | 69.8 | 93.9 | 115 | 215 | 150 | 108 | 177 | 178
Boiling point (°C) | 218 | 241 | 242 | 255 | 279 | 295 | 340 | 399 | 380 | 495 | 469^*^
Vapor pressure (mm Hg at 25°C) | 8.50 × 10^−2^ | 5.50 × 10^−2^ | 6.70 × 10^−2^ | 8.93 × 10^−3^ | 2.15 × 10^−3^ | 6.00 × 10^−4^ | 6.53 × 10^−6^ | 4.50 × 10^−6^ | 9.22 × 10^−6^ | 5.49 × 10^−9^ | 5.70 × 10^−9^
Henry’s law constant (atm-m^3^/mole at 25°C) | 4.4 × 10^−4^ | 5.18 × 10^−4^ | 5.14 × 10^−4^ | 3.08 × 10^−4^ | 1.84 × 10^−4^ | 9.62 × 10^−5^ | 5.56 × 10^−5^ | 1.19 × 10^−5^ | 8.86 × 10^−6^ | 4.57 × 10^−7^ | 1.07 × 10^−6^*
Water solubility (mol/L at 25°C) | 2.47 × 10^−4^ | 1.74 × 10^−4^ | 1.95 × 10^−4^ | 4.60 × 10^−5^ | 4.64 × 10^−5^ | 1.15 × 10^−5^ | 3.38 × 10^−7^ | 6.65 × 10^−7^ | 1.24 × 10^−6^ | 8.40 × 10^−9^ | 1.89 × 10^−8^
Log K_ow_ | 3.30 | 3.86 | 3.87 | 4.01 | 3.92 | 4.18 | 4.45 | 4.88 | 5.16 | 6.13 | 6.44
Log K_oa_ | 5.19 | 5.83^*^ | 5.01^*^ | 6.15 | 6.31 | 6.79 | 7.55 | 8.80 | 8.88 | 9.61^*^ | 10.3^*^
Log K_oc_ | 2.96 | 3.60 | 3.36 | 3.27 | 3.59 | 3.70 | 4.31 | 4.90 | 4.80 | 5.95 | 5.67^*^

a Data are presented as experimental averages from U.S. EPA CompTox Chemicals Dashboard unless otherwise stated; https://comptox.epa.gov/dashboard; updated 02-03-2021.

b EC number was developed by the TPHCWG and is proportional to the BP of a chemical. EC number is analogous to an n-paraffin retention time index and can be estimated using: EC = 4.12 + 0.02 (BP) + 6.5 × ^−^5 (BP)^2^ (NIST, 2020a; Edwards et al., 1997; Gustafson et al., 1997).

* Predicted value.

AC = anthracene; ANL = acenaphthene; BaP = benzo[a]pyrene; BeP = benzo[e]pyrene; BH = biphenyl; BP = boiling point; EC = equivalent carbon; FA = fluoranthene; FE = fluorene; K_oa_ = octanol-air partition coefficient; K_oc_ = soil adsorption coefficient; K_ow_ = octanol-water partition coefficient; 1MeNPT = 1-methylnaphthalene; 2MeNPT = 2-methylnaphthalene; NPT = naphthalene; Pyr = pyrene; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group; U.S. EPA = U.S. Environmental Protection Agency.

## 1.3 OVERVIEW OF MIXTURE ASSESSMENT METHODS

A number of different approaches have been developed and used to estimate risks and hazards posed by exposures to chemical mixtures encountered in the environment. The two approaches utilized in this PPRTV assessment are the indicator chemical approach and the hazard index (HI) approach. The choice of approaches is based on the available analytical chemistry.

The simplest of these approaches to implement is the indicator chemical approach ATSDR (2018). The indicator chemical approach estimates the risks or hazards of a mixture by evaluating the dose-response assessment developed for a component of the mixture and the exposure rate of the entire mixture. The indicator chemical approach is used when there are only measures of the concentrations of this fraction (i.e., no information is available on the concentrations of individual chemicals in this fraction).

In addition to the indicator chemical approach, the U.S. Environmental Protection Agency (EPA) Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures (U.S. EPA, 2000, 1986) describes the following two broad categories of approaches for assessing human health risks and health hazards associated with environmental exposures to chemical mixtures: component methods and whole mixture methods. Component-based approaches, which involve analyzing the toxicity of a mixture’s individual components, have more uncertainty and are recommended when appropriate toxicity data on a complex mixture of concern, or on a sufficiently similar mixture (discussed below), are unavailable (U.S. EPA, 2000, 1986). In this PPRTV assessment, a component approach, the HI approach, is described for assessing noncancer hazards posed by exposures to the aromatic high carbon range fraction.

Chemical mixture assessments are conducted most appropriately with quantitative dose-response information resulting from comparable exposures to the mixture of concern. If the dose-response data are insufficient to develop a health reference value for the specific mixture of concern in the environment, the second option recommended by the U.S. EPA Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures (U.S. EPA, 2000, 1986) is a “sufficient similarity” approach that uses a health reference value from a characterized surrogate mixture to estimate the hazards or risks associated with exposures to the mixture of concern. This method requires chemistry and toxicity data on both the potential surrogate mixture and the mixture of concern (e.g., an in vitro endpoint that is related to the apical endpoint observed in an epidemiological study or whole animal study), and a health reference value (e.g., from an in vivo study) on the surrogate mixture. If the chemistry and toxicity data indicate that the mixtures are “sufficiently similar” to one another, then the health reference value for the surrogate mixture can be used as a proxy for the mixture of concern. No data were identified that were suitable to implement a whole mixture approach.

The choice of a chemical mixtures risk assessment method is driven by the available data. Starting with the method requiring the least information and then discussing the method requiring more information, the following subsections summarize the indicator chemical approach and the HI approach. Figure 1 summarizes the two approaches and the preference for using each approach.

Figure 1 Provisional Peer-Reviewed Toxicity Approaches for the Aromatic High Carbon Range TPH Fraction Noncancer Assessment

Two approaches are available to estimate the noncancer hazards associated with exposure to the aromatic high carbon range fraction. Approach selection should be driven by the available exposure data. Increased analytical characterization of fraction components allows for more refined risk estimates with less inherent uncertainty. Approach preference is inversely correlated with approach uncertainty.

AC = anthracene; ANL = acenaphthene; BaP = benzo[a]pyrene; BH = 1,1-biphenyl; FA = fluoranthene; FE = fluorene; HQ = hazard quotient; 1MeNPT = 1-methylnaphthalene; 2MeNPT = 2-methylnaphthalene; NPT = naphthalene; Pyr = pyrene.

### 1.3.1 Indicator Chemical Approach

When the chemical composition of a mixture or a mixture fraction is not known, or toxicity measures are only available for a few individual chemicals in a mixture, the toxicity of an individual chemical can be used as an indicator for the toxicity of a mixture or a mixture fraction (ATSDR, 2018). ATSDR (2018) describes an indicator chemical as “a chemical … selected to represent the toxicity of a mixture because it is characteristic of other components in the mixture and has adequate dose-response data.” Indicator chemical approaches are typically implemented to assess health risks in a health-protective manner; the chemical chosen as an indicator is among the best characterized toxicologically and likely among the most toxic components of the mixture. The indicator chemical needs to have adequate dose-response data to indicate hazard potential or a dose-response relationship for noncancer outcomes, depending on the purpose of the assessment. The health risk value of the indicator chemical is integrated with exposure estimates for the mixture or mixture fraction to estimate health hazard associated with the fraction (i.e., calculate fraction-specific HI for a specific exposure pathway). This approach does not scale for potency of individual constituents; instead, it assumes that toxicity of all measured members of the fraction can be adequately estimated, given the purpose of the risk assessment, by the indicator chemical.

### 1.3.2 Hazard Index Approach

The HI approach combines estimated population exposures with toxicity information to characterize the potential for adverse effects. The HI is not a risk estimate, in that it is not expressed as a probability, nor is it an estimate of a toxicity measure (e.g., percentage decrement in enzyme activity). Instead, the HI is an indicator of potential hazard. In the HI approach, a hazard quotient (HQ) is calculated as the ratio of human exposure (E) to a health reference value (RfV) for each mixture component chemical (i) (U.S. EPA, 1986). These HQs are summed to yield the HI for the mixture. In health risk assessments, U.S. EPA’s preferred RfVs are the reference dose (RfD) for the oral exposure, and the reference concentration (RfC) for the inhalation exposure route.

H I = ∑_i = 1_^n^ H Q_i_ = ∑_i = 1_^n^ (E_i_)/(R f V_i_)

The HI is based on dose addition (U.S. EPA, 2000; Svendsgaard and Hertzberg, 1994); the hazard is evaluated as the potency-weighted sum of the component exposures. The HI is dimensionless, so E and the RfV must be in the same units.

1 Based on an empirical relationship, the EC value can be estimated from a compound’s boiling point (BP; °C) using the following equation: EC = 4.12 + 0.02 (BP) + 6.5 × 10^−5^ (BP)^2^; see Gustafson et al. (1997).