# APPENDIX D REFERENCES

Agarwal, P; Singh, L; Anand, M; Taneja, A. (2017). Association between placental polycyclic aromatic hydrocarbons (PAHS), oxidative stress, and preterm delivery: A case-control study. Arch Environ Contam Toxicol 74: 218–227. 10.1007/s00244-017-0455-0 28916946
Alhamdow, A; Lindh, C; Albin, M; Gustavsson, P; Tinnerberg, H; Broberg, K. (2017). Early markers of cardiovascular disease are associated with occupational exposure to polycyclic aromatic hydrocarbons. Sci Rep 7: 9426. 10.1038/s41598-017-09956-x 28842704
ATSDR (Agency for Toxic Substances and Disease Registry). (1995). Toxicological profile for polycyclic aromatic hydrocarbons - Update [ATSDR Tox Profile]. (CIS/97/00215). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. https://www.atsdr.cdc.gov/substances/toxsubstance.asp?toxid=25
ATSDR (Agency for Toxic Substances and Disease Registry). (2005). Toxicological profile for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. (PB2006100004). Atlanta, GA. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB2006100004
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Framework for assessing health impacts of multiple chemicals and other stressors (update). Washington, DC: U.S. Department of Health and Human Services. https://www.atsdr.cdc.gov/interactionprofiles/ip-ga/ipga.pdf
Baxter, CS; Warshawsky, D. (2012). Polycyclic aromatic hydrocarbons and azaaromatic compounds. In E Bingham; B Cohrssen (Eds.), Patty’s toxicology: Volume 2 (6th ed., pp. 371-428). New York: John Wiley & Sons, Inc. 10.1002/0471435139.tox052.pub2
Benninghoff, AD; Williams, DE. (2013). The role of estrogen receptor β in transplacental cancer prevention by indole-3-carbinol. Cancer Prev Res 6: 339–348. 10.1158/1940-6207.CAPR-12-0311
Boogaard, PJ; Carrillo, JC; Roberts, LG; Whale, GF. (2017). Toxicological and ecotoxicological properties of gas-to-liquid (GTL) products. 1. Mammalian toxicology [Review]. Crit Rev Toxicol 47: 121–144. 10.1080/10408444.2016.1214676 27559992
Castro, DJ; Baird, WM; Pereira, CB; Giovanini, J; Löhr, CV; Fischer, KA; Yu, Z; Gonzalez, FJ; Krueger, SK; Williams, DE. (2008a). Fetal mouse CYP1B1 and transplacental carcinogenesis from maternal exposure to dibenzo(a,l)pyrene. Cancer Prev Res 1: 128–134. 10.1158/1940-6207.CAPR-07-0004
Castro, DJ; Löhr, CV; Fischer, KA; Pereira, CB; Williams, DE. (2008b). Lymphoma and lung cancer in offspring born to pregnant mice dosed with dibenzo[a,l]pyrene: the importance of in utero vs. lactational exposure. Toxicol Appl Pharmacol 233: 454–458. 10.1016/j.taap.2008.09.009 18848954
Castro, DJ; Löhr, CV; Fischer, KA; Waters, KM; Webb-Robertson, BJ; Dashwood, RH; Bailey, GS; Williams, DE. (2009). Identifying efficacious approaches to chemoprevention with chlorophyllin, purified chlorophylls and freeze-dried spinach in a mouse model of transplacental carcinogenesis. Carcinogenesis 30: 315–320. 10.1093/carcin/bgn280 19073876
Castro, DJ; Yu, Z; Löhr, CV; Pereira, CB; Giovanini, JN; Fischer, KA; Orner, GA; Dashwood, RH; Williams, DE. (2008c). Chemoprevention of dibenzo[a,l]pyrene transplacental carcinogenesis in mice born to mothers administered green tea: primary role of caffeine. Carcinogenesis 29: 1581–1586. 10.1093/carcin/bgm237 18635525
Chu, S; Zhang, H; Maher, C; McDonald, JD; Zhang, X; Ho, SM; Yan, B; Chillrud, S; Perera, F; Factor, P; Miller, RL. (2013). Prenatal and postnatal polycyclic aromatic hydrocarbon exposure, airway hyperreactivity, and beta-2 adrenergic receptor function in sensitized mouse offspring. J Toxicol 2013: 603581. 10.1155/2013/603581 24454363
CITI (Chemicals Inspection and Testing Institute Japan). (1992). Biodegradation and bioaccumulation data of existing chemicals based on the CSCL Japan, with cover letter dated 01/19/95. Tokyo, Japan: Chemical Industry Ecology-Toxicology and Information Center. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557584.xhtml
Clark, JD, III; Serdar, B; Lee, DJ; Arheart, K; Wilkinson, JD; Fleming, LE. (2012). Exposure to polycyclic aromatic hydrocarbons and serum inflammatory markers of cardiovascular disease [Review]. Environ Res 117: 132–137. 10.1016/j.envres.2012.04.012 22626472
Crepeaux, G; Bouillaud-Kremarik, P; Sikhayeva, N; Rychen, G; Soulimani, R; Schroeder, H. (2012). Late effects of a perinatal exposure to a 16 PAH mixture: Increase of anxiety-related behaviours and decrease of regional brain metabolism in adult male rats. Toxicol Lett 211: 105–113. 10.1016/j.toxlet.2012.03.005 22450773
Crepeaux, G; Bouillaud-Kremarik, P; Sikhayeva, N; Rychen, G; Soulimani, R; Schroeder, H. (2013). Exclusive prenatal exposure to a 16 PAH mixture does not impact anxiety-related behaviours and regional brain metabolism in adult male rats: A role for the period of exposure in the modulation of PAH neurotoxicity. Toxicol Lett 221: 40–46. 10.1016/j.toxlet.2013.05.014 23742931
Crepeaux, G; Bouillaud-Kremarik, P; Sikhayeva, N; Rychen, G; Soulimani, R; Schroeder, H. (2014). Short-term effects of a perinatal exposure to a 16 polycyclic aromatic hydrocarbon mixture in rats: Assessment of early motor and sensorial development and cerebral cytochrome oxidase activity in pups. Neurotoxicology 43: 90–101. 10.1016/j.neuro.2014.03.012 24709092
Dalbey, WE; McKee, RH; Goyak, KO; Charlap, JH; Parker, C; White, R. (2014). Subchronic and developmental toxicity of aromatic extracts. Int J Toxicol 33: 136S–155S. 10.1177/1091581813517724 24567345
Dodd, DE; Wong, BA; Gross, EA; Miller, RA. (2012). Nasal epithelial lesions in F344 rats following a 90-day inhalation exposure to naphthalene. Inhal Toxicol 24: 70–79. 10.3109/08958378.2011.636086 22182220
ECHA (European Chemicals Agency). (2019). Substance evaluation conclusion as required by reach article 48 and evaluation report for biphenyl, EC no 202-163-5, CAS no 92-52-4, evaluating member state(s): Portugal. https://echa.europa.eu/documents/10162/5795770e-ba49-26d6-2ae4-57fbe2408459
Edwards, DA; Andriot, MD; Amoruso, MA; Tummey, AC; Bevan, CJ; Tveit, A; Hayes, LA; Youngren, SH; Nakles, DV. (1997). Total petroleum hydrocarbon criteria working group series: Volume 4: Development of fraction specific reference doses (RFDs) and reference concentrations (RFCs) for total petroleum hydrocarbons (TPH). Amherst, MA: Amherst Scientific Publishers.
Fish, TJ; Benninghoff, AD. (2017a). Data on the effect of in utero exposure to polycyclic aromatic hydrocarbons on genome-wide patterns of DNA methylation in lung tissues. Data in Brief 13: 498–513. 10.1016/j.dib.2017.06.023 28702489
Fish, TJ; Benninghoff, AD. (2017b). DNA methylation in lung tissues of mouse offspring exposed in utero to polycyclic aromatic hydrocarbons. Food Chem Toxicol 109: 703–713. 10.1016/j.fct.2017.04.047 28476633
Gagnaire, F; Marignac, B; de Ceaurriz, J. (1993). Triethylbenzene-induced sensorimotor neuropathy in rats. J Appl Toxicol 13: 123–128. 10.1002/jat.2550130209 8486910
Gustafson, JB; Griffith Tell, J; Orem, D. (1997). Total petroleum hydrocarbon criteria working group series: Volume 3: Selection of representative TPH fractions based on fate and transport considerations. Amherst, MA: Amherst Scientific Publishers. https://netforum.avectra.com/eweb/shopping/shopping.aspx?pager=1&site=aehs&webcode=shopping&prd_key=146b7eaf-c92d-4e4b-af1f-092c5735a10b
IARC (International Agency for Research on Cancer). (2010). Some non-heterocyclic polycyclic aromatic hydrocarbons and some related exposures [IARC Monograph]. Lyon, France. http://monographs.iarc.fr/ENG/Monographs/vol92/mono92.pdf
Keith, LH. (2015). The source of US EPA’s sixteen PAH priority pollutants. Polycycl Aromat Compd 35: 147–160. 10.1080/10406638.2014.892886
Kim, A; Park, M; Yoon, TK; Lee, WS; Ko, JJ; Lee, K; Bae, J. (2011). Maternal exposure to benzo[b]fluoranthene disturbs reproductive performance in male offspring mice. Toxicol Lett 203: 54–61. 10.1016/j.toxlet.2011.03.003 21392559
Madeen, EP; Löhr, CV; You, H; Siddens, LK; Krueger, SK; Dashwood, RH; Gonzalez, FJ; Baird, WM; Ho, E; Bramer, L; Waters, KM; Williams, DE. (2016). Dibenzo[def,p]chrysene transplacental carcinogenesis in wild-type, CYP1B1 knockout, and CYP1B1 humanized mice. Mol Carcinog 56: 163–171. 10.1002/mc.22480 26990437
MassDEP (Massachusetts Department of Environmental Protection). (2003). Updated petroleum hydrocarbon fraction toxicity values for the VPH/EPH/APH methodology. Boston, MA. https://www.mass.gov/files/documents/2016/08/ok/tphtox03.pdf
Mckee, RH; Adenuga, MD; Carrillo, JC. (2015). Characterization of the toxicological hazards of hydrocarbon solvents [Review]. Crit Rev Toxicol 45: 273–365. 10.3109/10408444.2015.1016216 25868376
Mihelcic, JR; Luthy, RG. (1988). Microbial degradation of acenaphthene and naphthalene under denitrification conditions in soil-water systems. Appl Environ Microbiol 54: 1188–1198. 10.1128/AEM.54.5.1188-1198.1988 3389812
Mortamais, M; Pujol, J; van Drooge, BL; Macià, D; Martínez-Vilavella, G; Reynes, C; Sabatier, R; Rivas, I; Grimalt, J; Forns, J; Alvarez-Pedrerol, M; Querol, X; Sunyer, J. (2017). Effect of exposure to polycyclic aromatic hydrocarbons on basal ganglia and attentiondeficit hyperactivity disorder symptoms in primary school children. Environ Int 105: 12–19. 10.1016/j.envint.2017.04.011 28482185
NIST (National Institute of Standards and Technology). (2020a). NIST 17 GC method/retention index library [Database]. Retrieved from https://chemdata.nist.gov/dokuwiki/doku.php?id=chemdata:ridatabase
NIST (National Institute of Standards and Technology). (2020b). NIST special publication 922: Polycyclic aromatic hydrocarbon structure index. U.S. Department of Commerce Technology Administration. https://www.nist.gov/system/files/documents/2020/08/03/sp922_2020.pdf
NJ DEP (New Jersey Department of Environmental Protection). (2010). Analysis of extractable petroleum hydrocarbon compounds (EPH) in aqueous and soil/sediment/sludge matrices (Revision 3 ed.). (NJDEP EPH 10/08). New Jersey Department of Environmental Protection Site Remediation Program Office of Data Quality. https://www.nj.gov/dep/srp/guidance/srra/eph_method.pdf
NLM (National Library of Medicine). (2005). Hazardous substances data bank. Biphenyl. CASRN: 92-52-4. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/530
NLM (National Library of Medicine). (2014). Hazardous substances data bank. Naphthalene, CASRN: 91-20-3. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/184
NLM (National Library of Medicine). (2015a). Hazardous substances data bank. 1-Methylnaphthalene, CASRN: 90-12-0. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5268
NLM (National Library of Medicine). (2015b). Hazardous substances data bank. 2-Methylnaphthalene, CASRN: 91-57-6. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5274
NLM (National Library of Medicine). (2017a). Hazardous substances data bank. Acenaphthene, CASRN: 83-32-9. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/2659
NLM (National Library of Medicine). (2017b). Hazardous substances data bank. Anthracene, CASRN: 120-12-7. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/702
NLM (National Library of Medicine). (2017c). Hazardous substances data bank. Benzo(a)pyrene, CASRN: 50-32-8. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/2554
NLM (National Library of Medicine). (2017d). Hazardous substances data bank. Dibenzo(a,l)pyrene, CASRN: 191-30-0. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/4029
NLM (National Library of Medicine). (2017e). Hazardous substances data bank. Fluoranthene, CASRN: 206-44-0. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/5486
NLM (National Library of Medicine). (2017f). Hazardous substances data bank. Fluorene, CASRN: 86-73-7. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/2165
NLM (National Library of Medicine). (2017g). Hazardous substances data bank. Pyrene, CASRN: 129-00-0. Bethesda, MD. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/4023
NTP (National Toxicology Program). (2000). NTP technical report on the toxicology and carcinogenesis studies of naphthalene (CAS no. 91-20-3) in F344/N rats (inhalation studies) (pp. 1-173). (NTP TR 500). Research Triangle Park, NC.
OECD (Organisation for Economic Co-operation and Development). (2007). SIDS initial assessment profile: CAS No. 25340-17-4. Chemical name: Diethylbenzene, mixed isomers (DEB mixed isomers). https://hpvchemicals.oecd.org/UI/handler.axd?id=2bb369a1-c6e1-4494-ac56-6ad188d4e5ec
OECD (Organisation for Economic Co-operation and Development). (2009). OECD guidelines for testing of chemicals, section 3: Test no. 302C: Inherent biodegradability: Modified MITI test (II). https://www.oecd-ilibrary.org/environment/test-no-302c-inherent-biodegradability-modified-miti-test-ii_9789264070400-en;jsessionid=c_rFvNFZV9AkfK39UkdmECex.ip-10-240-5-187
OECD (Organisation for Economic Co-operation and Development). (2012). SIDS initial assessment profile. Chemical category: C10-C13 aromatic hydrocarbon solvents category. CAS number and chemical names. Solvent naphtha, (petroleum), heavy aromatic: 64742-94-5. Hydrocarbons, C10, aromatics, >1% naphthalene. Hydrocarbons, C10, aromatics, <1% naphthalene. Hydrocarbons, C10-C13, aromatics, >1% naphthalene. Hydrocarbons, C10-C13, aromatics, <1% naphthalene. C9-10 aromatics, predominantly C9-C10 alkylbenzenes and naphthalene. Aromatics hydrocarbons, C9 – 11: 70693-06-0. Napthalane, methyl (mixed) 1321-94-4. Hydrocarbons, C11, aromatics. https://hpvchemicals.oecd.org/ui/handler.axd?id=884A80E0-A657-48CD-8748-CD361A682D06
Peiffer, J; Grova, N; Hidalgo, S; Salquèbre, G; Rychen, G; Bisson, JF; Appenzeller, BM; Schroeder, H. (2016). Behavioral toxicity and physiological changes from repeated exposure to fluorene administered orally or intraperitoneally to adult male Wistar rats: A dose-response study. Neurotoxicology 53: 321–333. 10.1016/j.neuro.2015.11.006 26616911
Ranjbar, M; Rotondi, MA; Ardern, CI; Kuk, JL. (2015). Urinary biomarkers of polycyclic aromatic hydrocarbons are associated with cardiometabolic health risk. PLoS ONE 10: e0137536. 10.1371/journal.pone.0137536 26340343
Shell Global Solutions International; Bonte, M; Gill, R; Dawick, J; Boogaard, PJ. (2017). Heavy hydrocarbon fate and transport in the environment. Quarterly Journal of Engineering Geology and Hydrogeology 50: 333.
Shorey, LE; Castro, DJ; Baird, WM; Siddens, LK; Löhr, CV; Matzke, MM; Waters, KM; Corley, RA; Williams, DE. (2012). Transplacental carcinogenesis with dibenzo[def,p]chrysene (DBC): Timing of maternal exposures determines target tissue response in offspring. Cancer Lett 317: 49–55. 10.1016/j.canlet.2011.11.010 22085489
Shorey, LE; Madeen, EP; Atwell, LL; Ho, E; Löhr, CV; Pereira, CB; Dashwood, RH; Williams, DE. (2013). Differential modulation of dibenzo[def,p]chrysene transplacental carcinogenesis: Maternal diets rich in indole-3-carbinol versus sulforaphane. Toxicol Appl Pharmacol 270: 60–69. 10.1016/j.taap.2013.02.016 23566957
Slotkin, TA; Skavicus, S; Card, J; Giulio, RT; Seidler, FJ. (2017). In vitro models reveal differences in the developmental neurotoxicity of an environmental polycylic aromatic hydrocarbon mixture compared to benzo[a]pyrene: Neuronotypic PC12 Cells and embryonic neural stem cells. Toxicology 377: 49–56. 10.1016/j.tox.2016.12.008 28049045
Sram, RJ; Veleminsky, M; Veleminsky, M; Stejskalová, J. (2017). The impact of air pollution to central nervous system in children and adults [Review]. Neuro Endocrinol Lett 38: 389–396.29298278
Suresh, R; Shally, A; Mahdi, AA; Patel, DK; Singh, VK; Rita, M. (2009). Assessment of association of exposure to polycyclic aromatic hydrocarbons with bronchial asthma and oxidative stress in children: A case control study. Indian J Occup Environ Med 13: 33–37. 10.4103/0019-5278.50722 20165611
Svendsgaard, DJ; Hertzberg, RC. (1994). Statistical methods for the toxicological evaluation of the additivity assumption as used in the Environmental Protection Agency chemical mixture risk assessment guidelines. In RSH Yang (Ed.), Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches (pp. 599-642). San Diego, CA: Academic Press.
Swiercz, R; Wąsowicz, W; Stetkiewicz, J; Gromadzińska, J; Majcherek, W. (2011). 4-Week inhalation toxicity of 2-methylnaphthalene in experimental animals. Int J Occup Med Environ Health 24: 399–408. 10.2478/s13382-011-0036-9 22002322
Tshala-Katumbay, DD; Palmer, VS; Lasarev, MR; Kayton, RJ; Sabri, MI; Spencer, PS. (2006). Monocyclic and dicyclic hydrocarbons: structural requirements for proximal giant axonopathy. Acta Neuropathol 112: 317–324. 10.1007/s00401-006-0106-4 16874529
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for the health risk assessment of chemical mixtures (pp. 1-38). (EPA/630/R-98/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=22567
U.S. EPA (U.S. Environmental Protection Agency). (1990a). Integrated Risk Information System (IRIS) chemical assessment summary for acenaphthene (CASRN 83-32-9). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0442_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990b). Integrated Risk Information System (IRIS) chemical assessment summary for anthracene (CASRN 120-12-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0434_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990c). Integrated Risk Information System (IRIS) chemical assessment summary for fluoranthene (CASRN 206-44-0). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0444_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990d). Integrated Risk Information System (IRIS) chemical assessment summary for fluorene (CASRN 86-73-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0435_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990e). Integrated Risk Information System (IRIS) chemical assessment summary for pyrene (CASRN 129-00-0). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0445_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1997). Toxicological review of cumene (CAS no. 98-82-8) in support of summary information on the Integrated Risk Information System [EPA Report]. (EPA63SR98001). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0306tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1998). Toxicological review of naphthalene (CAS no. 91-20-3) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. Washington, DC: Integrated Risk Information System. https://iris.epa.gov/static/pdfs/0436tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2000). Supplementary guidance for conducting health risk assessment of chemical mixtures (pp. 1-209). (EPA/630/R-00/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=20533
U.S. EPA (U.S. Environmental Protection Agency). (2003). Toxicological review of 2-methylnaphthalene (CASRN 91-57-6) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R03010). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1006tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Toxicological review of n-hexane (CAS no. 110-54-3) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-03/012). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0486tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2007a). Provisional peer-reviewed toxicity values for 2-methylnaphthalene (CASRN 91-57-6) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Methylnaphthalene2.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2007b). Provisional peer-reviewed toxicity values for pyrene (CASRN 129-00-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Pyrene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2008). Provisional peer-reviewed toxicity values for 1-methylnaphthalene (CASRN 90-12-0) [EPA Report]. (EPA/690/R-08/017F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/recordisplay.cfm?deid=338997
U.S. EPA (U.S. Environmental Protection Agency). (2009a). Provisional peer-reviewed toxicity values for anthracene (CASRN 120-12-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Anthracene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009b). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/ComplexMixturesofAliphaticandAromaticHydrocarbons.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009c). Provisional peer-reviewed toxicity values for phenanthrene (CASRN 85-01-8) [EPA Report]. (EPA690R09045F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Phenanthrene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Provisional peer-reviewed toxicity values for 1,1-biphenyl (CASRN 92-52-4) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Biphenyl11.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Provisional peer-reviewed toxicity values for acenaphthene (CASRN 83-32-9) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Acenaphthene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012). Provisional peer-reviewed toxicity values for fluoranthene (CASRN 206-44-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Fluoranthene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2013). Toxicological review of biphenyl (CAS 92-52-4). In support of summary information on the Integrated Risk Information System (IRIS). (EPA/635/R-11/005F). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/risk/hhra/recordisplay.cfm?deid=247853
U.S. EPA (U.S. Environmental Protection Agency). (2017a). Toxicological review of benzo[a]pyrene (CASRN 50-32-8) [EPA Report]. (EPA635R17003Fa). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0136tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2017b). Toxicological review of benzo[a]pyrene (CASRN 50-32-8): Supplemental information [EPA Report]. (EPA635R17003Fb). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/si/si_public_file_download.cfm?p_download_id=535926&Lab=NCEA
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox chemicals dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Provisional peer-reviewed toxicity values for benzo[e]pyrene (BeP) (CASRN 192-97-2). (EPA/690/R-21/008F). Cincinnati, OH: Center for Public Health and Environmental Assessment.
U.S. EPA (U.S. Environmental Protection Agency). (2021c). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) - DRAFT IN PROGRESS [EPA Report]. Cincinnati, OH.
U.S. EPA (U.S. Environmental Protection Agency). (2021d). Toxic and priority pollutants under the Clean Water Act. Available online at https://www.epa.gov/eg/toxic-and-priority-pollutants-under-clean-water-act
U.S. EPA (U.S. Environmental Protection Agency). (2022). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH.
Wang, B; Li, Z; Ma, Y; Qiu, X; Ren, A. (2016). Association of polycyclic aromatic hydrocarbons in housewives’ hair with hypertension. Chemosphere 153: 315–321. 10.1016/j.chemosphere.2016.03.067 27023119
Wang, NCY; Rice, GE; Teuschler, LK; Colman, J; Yang, RSH. (2012). An in silico approach for evaluating a fraction-based, risk assessment method for total petroleum hydrocarbon mixtures. J Toxicol 2012: 410143. 10.1155/2012/410143 22496687
Weyand, EH; Parimoo, B; Reuhl, KR; Goldstein, LS; Wang, JQ; Harvey, RG. (2004). 7H-benzo[c]fluorene: A potent systemic lung carcinogen. Polycycl Aromat Compd 24: 1–20. 10.1080/10406630490426942
Xu, X; Cook, RL; Ilacqua, VA; Kan, H; Talbott, EO; Kearney, G. (2010). Studying associations between urinary metabolites of polycyclic aromatic hydrocarbons (PAHs) and cardiovascular diseases in the United States. Sci Total Environ 408: 4943–4948. 10.1016/j.scitotenv.2010.07.034 20701951
Yan, Z; Zhang, H; Maher, C; Arteaga-Solis, E; Champagne, FA; Wu, L; McDonald, JD; Yan, B; Schwartz, GJ; Miller, RL. (2014). Prenatal polycyclic aromatic hydrocarbon, adiposity, peroxisome proliferator-activated receptor (PPAR) γ methylation in offspring, grand-offspring mice. PLoS ONE 9: e110706. 10.1371/journal.pone.0110706 25347678
Yang, P; Wang, YX; Sun, L; Chen, YJ; Liu, C; Huang, LL; Lu, WQ; Zeng, Q. (2017). Urinary metabolites of polycyclic aromatic hydrocarbons, sperm DNA damage and spermatozoa apoptosis. J Hazard Mater 329: 241–248. 10.1016/j.jhazmat.2017.01.053 28178639
Yin, S; Tang, M; Chen, F; Li, T; Liu, W. (2017). Environmental exposure to polycyclic aromatic hydrocarbons (PAHs): The correlation with and impact on reproductive hormones in umbilical cord serum. Environ Pollut 220: 1429–1437. 10.1016/j.envpol.2016.10.090 27838061