# APPENDIX C POTENTIALLY RELEVANT NONCANCER EVIDENCE

In order to assess consistency in effects and potency across the components of the fraction, experimental data from compound-specific Integrated Risk Information System (IRIS) and Provisional Peer-Reviewed Toxicity Value (PPRTV) assessment documents and primary data sources (identified from literature searches) were used to create exposure-response arrays. Data were extracted only from studies meeting existing IRIS and PPRTV program standards that provided dose-response data enabling the identification of no-observed-adverse-effect levels (NOAELs) and lowest-observed-adverse-effect levels (LOAELs). Target organ-specific NOAELs and LOAELs were determined using the following methodology.

1. Whenever possible, NOAELs and LOAELs were identified from existing IRIS or PPRTV assessments. For chemicals in which both types of assessments were available, preference was given to IRIS (in accordance with the U.S. Environmental Protection Agency [U.S. EPA] Office of Superfund Remediation and Technology Innovation [OSRTI] hierarchy of human health toxicity values for Superfund assessments). In general, these assessments explicitly identified NOAEL and LOAEL values only for the most sensitive target of toxicity.
2. All other target-organ-specific effect levels (i.e., for targets other than the most sensitive target identified in IRIS or PPRTV assessments, and all targets evaluated in newly identified studies) were determined using professional judgment, taking into consideration factors such as statistical significance (at a p-value < 0.05), biological significance (e.g., a greater than 10% increase in liver weight), magnitude and direction of change, and study quality. In the case of chemicals with existing IRIS or PPRTV assessments, NOAELs and LOAELs could often be identified from existing study summaries.

Dose-response data were presented in exposure-response arrays by health outcome and exposure route. From left to right, compounds exhibiting an effect typically are shown before those not exhibiting an effect, to enable identification of patterns. For compounds that do not exhibit an effect, NOAELs in the arrays are ordered by equivalent carbon (EC) number (low to high from left to right), with mixtures shown last. Both administered doses and exposure concentrations reported in the arrays and in the text reflect time-weighted average (TWA) exposures to facilitate comparisons across studies and compounds. Consistency across the fraction was evaluated by assessing if comparable outcomes were observed for members of the fraction, and if these effects were observed at similar dose levels.

Unless otherwise specified, the term “significant,” used throughout this appendix, refers to statistical significance at a p-value of <0.05.

## BODY-WEIGHT EFFECTS

Decreased body-weight gain was the critical effect in the study used to derive the chronic reference dose (RfD) for naphthalene (U.S. EPA, 1998). No human studies examining body-weight effects of aromatic high carbon range compounds were identified in the sources reviewed. As shown in Table 5, animal studies that examined body-weight gain as an endpoint are available for nearly all of the compounds and mixtures with toxicity data; exceptions are benzo[e]pyrene [BeP], dibenzo[def,p]chrysene, and the 16- and 9-polycyclic aromatic hydrocarbon (PAH) mixtures. In this section, body-weight decreases of at least 10% relative to controls in adult animals are considered LOAELs, and smaller changes are not. For studies that reported body-weight gain but did not report absolute body weights, and for studies of maternal weight gain during gestation, statistically significant changes from control are described.

### Animal Studies

Figures C-1, C-2, and C-3 show the effects of orally-administered aromatic high carbon range compounds on body weight following subchronic exposure, body weight following chronic exposure, and maternal body weight after gestational exposure, respectively. Data are available for 14 compounds, including compounds with carbon (C) numbers C10−C20. Body-weight decreases were observed after exposure to several compounds across the fraction, including naphthalene, 1,1-biphenyl, 1,2,4-triethylbenzene, fluorene, fluoranthene, and benzo[a]pyrene (BaP) (U.S. EPA, 2017a, b, 2013, 2012, 2011a; Tshala-Katumbay et al., 2006; U.S. EPA, 1998, 1990d). The lowest reported LOAELs (by compound) ranged from 0.7 mg/kg-day (BaP) to 1,500 mg/kg-day (fluoranthene) in subchronic studies (see Figure C-1). Body-weight data for chronic exposures were limited, with significant body-weight reductions reported for 1,1-biphenyl at a wide range of LOAELs (7−378 mg/kg-day in rats, ≥291 mg/kg-day in mice) (U.S. EPA, 2013) and for BaP at a LOAEL of 21 mg/kg-day in rats (U.S. EPA, 2017a, b). No body-weight effects were reported after chronic exposure for the remaining tested compounds (see Figure C-2). In gestational studies, the lowest reported LOAELs, for reduced maternal body weight or body-weight gain, were 150 mg/kg-day for naphthalene and 1,000 mg/kg-day for 1,1-biphenyl. No body-weight effects were reported after gestational exposure for the remaining tested compounds (see Figure C-3).

Figure C-1 Body-Weight Effects in Animals after Subchronic (4–16 Weeks) Oral Exposure to Aromatic High Carbon Range Compounds

Figure C-2 Body-Weight Effects in Animals after Chronic (≥24 Week) Oral Exposure to Aromatic High Carbon Range Compounds

Figure C-3 Maternal Body-Weight Effects in Animals after Gestational Oral Exposure to Aromatic High Carbon Range Compounds

Data for body-weight effects following oral exposure to mixtures are available from one study (not included in the body-weight exposure-response graphs). In this study, no body-weight effects were noted in mice exposed to a 21-PAH mixture with or without benzo[c]fluorene in the diet for 37 weeks at doses of approximately 15−17 mg/kg-day (Weyand et al., 2004).

Body-weight data following inhalation exposure were only available for four aromatic high carbon range compounds with carbon numbers C10−C20: naphthalene, 1,1-biphenyl, 2-methylnaphthalene, and BaP. An exposure-response graph to compare potencies across compounds was not included due to limited data. Decreased body weight was reported in rats exposed to 1,1-biphenyl at 60 mg/m^3^, a concentration associated with 50% mortality. Mice and rabbits exposed to similar concentrations did not show body-weight effects (or changes in survival) (U.S. EPA, 2013). No body-weight effects were reported following inhalation exposure to other tested compounds (U.S. EPA, 2017a, b; Dodd et al., 2012; Swiercz et al., 2011; ATSDR, 2005; U.S. EPA, 1998).

### Summary of Potentially Relevant Evidence

No human data are available for body-weight effects. Compounds across the aromatic high carbon range fraction have been shown to reduce body weights in rats, mice, and rabbits following oral exposure. Compounds associated with body-weight effects following oral route exposures include carbon numbers C10 (naphthalene) to C20 (BaP), with naphthalene having the lowest LOAEL following gestational exposure, BaP having the lowest LOAEL following subchronic exposure, and 1,1-biphenyl (C12) having the lowest LOAEL following chronic exposure. Compounds not associated with body-weight effects also spanned the high carbon range, including carbon numbers C11 (1,3,5-triethylbenzene) to C20 (benzo[b]fluoranthene). Taken together, these data suggest that oral exposure to many aromatic high carbon range fraction compounds can cause decreases in body weight, but no apparent pattern of sensitivity is observed based on number of carbons or ring structure. Available inhalation data do not report body-weight effects following inhalation exposure to naphthalene, 1,1-biphenyl, 2-methylnaphthalene, or BaP at nonlethal concentrations.

## HEMATOLOGICAL EFFECTS

Decreased red blood cells (RBCs), hemoglobin (Hb), and packed cell volume (PCV) were the critical effects in the study used to derive the chronic reference dose (RfD) for fluorene (U.S. EPA, 1997, 1990d). Hematological alterations (decreased PCV) were also considered cocritical effects in the study used to derive the chronic RfD for fluoranthene (U.S. EPA, 1990c). Human data pertaining to hematological effects of aromatic high carbon range fraction members are limited primarily to case reports of naphthalene exposure. As shown in Table 5, data on hematological effects in animals were located for 10 members of the fraction.

### Human Studies

Hemolytic anemia has been reported in adults, children, and neonates exposed to naphthalene by ingestion, inhalation, and dermal contact with clothes and bedding impregnated with naphthalene from moth balls (ATSDR, 2005; U.S. EPA, 1998). It has also been reported in newborns exposed transplacentally during pregnancy. Blood samples from patients with anemia exhibited reduced Hb, hematocrit (Hct), and RBC values and increased reticulocytes, Heinz bodies, serum bilirubin, and fragmented RBCs. Hemolytic anemia was accompanied by jaundice, cyanosis, and kernicterus with neurological signs in severe cases (U.S. EPA, 1998). Individuals with a deficiency in the enzyme, glucose-6-phosphate dehydrogenase (G6PDH), are particularly susceptible to naphthalene-induced hemolytic anemia (ATSDR, 2005; U.S. EPA, 1998). No data are available regarding potential hematological effects in humans for other members of the fraction.

### Animal Studies

Hemolytic anemia was reported in one dog given a single oral dose of 1,525 mg/kg naphthalene in food and in another given 263 mg/kg-day naphthalene in food for 7 days (ATSDR, 2005). These data provide limited evidence of hemolytic anemia in dogs following acute or short-term exposure to naphthalene at high doses. Studies in rats and mice did not find evidence of hemolytic anemia following acute naphthalene exposure (ATSDR, 2005). Figure C-4 shows the effects of orally-administered naphthalene and other aromatic high carbon range compounds on hematological parameters in subchronic and chronic animal studies (studies available only in rodents). Data are available for 10 compounds, including compounds with carbon numbers C10−C20. Hematological alterations were seen with several compounds across the fraction following subchronic oral exposure, including decreases in RBC, Hct/PCV, and/or Hb (BaP, fluorene, fluoranthene) and inconsistent alterations in white blood cell (WBC) populations (naphthalene, fluoranthene, acenaphthene) (U.S. EPA, 2017a, b, 2012, 1998, 1990a, c, d). The lowest LOAELs (by compound) for RBC effects ranged from 7.1 to 250 mg/kg-day, and the lowest LOAELs for WBC effects ranged from 143 to 1,500 mg/kg-day. No hematological alterations were observed following subchronic oral exposure to pyrene or anthracene (NOAELs of 250 and 1,000 mg/kg-day, respectively) (U.S. EPA, 1990b, e). Chronic oral data are limited to three compounds (1-methylnaphthalene, 2-methylnaphthalene, 1,1-biphenyl), none of which showed hematological effects (see Figure C-4) (U.S. EPA, 2013; ATSDR, 2005).

Figure C-4 Hematological Effects in Animals after Oral Exposure to Aromatic High Carbon Range Compounds

Data pertaining to the effects of inhalation exposure to aromatic high carbon range compounds on hematological parameters are limited to naphthalene and 2-methylnaphthalene. An exposure-response graph to compare potencies across compounds was not included due to the limited data. In contrast to effects seen after oral exposure to fraction components, stimulation of the hematopoietic system was observed following inhalation exposure to 2-methylnaphthalene at concentrations ranging from 0.4 to 8.9 mg/m^3^ for 4 weeks (Swiercz et al., 2011). Observed effects included exposure-related trends for increased RBC counts, Hct, and Hb in male rats, as well as increased reticulocyte abundance in male and female rats. No exposure-related changes in hematological parameters were observed in mice following exposure to naphthalene at 28 mg/m^3^ for 2 weeks (ATSDR, 2005; U.S. EPA, 1998).

### Summary of Potentially Relevant Evidence

Available human data indicate that acute exposures to high levels of naphthalene via oral, inhalation, or dermal routes may cause hemolytic anemia, particularly in individuals with G6PDH enzyme deficiency. Available animal data indicate that dogs, but not rodents, may also be susceptible to hemolytic anemia following acute oral exposure to naphthalene. Data in laboratory animals indicate that anemia (decreased RBC count, Hct/PCV, and/or Hb) may occur following subchronic oral exposure to compounds from across the high fraction, including BaP, fluorene, and fluoranthene (C13−C20). Data regarding potential alterations in WBC parameters following oral exposure are inconsistent between and within studied fraction members (see Figure C-4). Too few studies are available to evaluate effects and potencies in animals after inhalation exposure. Taken together, the data indicate that oral exposure to some aromatic high carbon range fraction compounds may result in anemia, and effects may be severe in humans following acute exposure to high levels of naphthalene via any route.

## NEUROLOGICAL EFFECTS

Clinical signs of toxicity in pregnant dams, including central nervous system (CNS) depression, are the critical effects for the intermediate minimal risk level (MRL) for naphthalene (ATSDR, 2005). Neurodevelopmental effects are the critical effect for the chronic RfD for BaP; however, these effects are discussed below in the developmental section. Neurological effects in humans have been studied in coke oven workers exposed to complex PAH mixtures and workers exposed to 1,1-biphenyl during production of 1,1-biphenyl-impregnated fruit wrapping paper. As shown in Table 5, data on neurological effects in animals were identified for 12 members of the fraction; however, the studies varied widely with respect to the nature of the neurological endpoints evaluated.

### Human Studies

Neurobehavioral examinations of coke oven workers exposed to complex PAH mixtures demonstrated impairments in short-term memory and attention and deficits in sensorimotor coordination, and some effects were directly correlated with measured air levels of BaP (U.S. EPA, 2017a, b). Occupational workers exposed to 1,1-biphenyl in Finland had abnormal electroencephalography (EEG), nerve conduction velocity, and electromyographic (EMG) test results. A study of similarly exposed workers in Sweden did not demonstrate neurological test abnormalities; however, an increase in the relative risk of Parkinson’s disease was reported (U.S. EPA, 2013).

### Animal Studies

Figure C-5 shows the effects of subchronic oral exposure to aromatic high carbon range compounds on neurological parameters. Subchronic data are available for eight compounds, including compounds with carbon numbers C10−C20. Neurobehavioral alterations and/or clinical signs of neurotoxicity were observed with several compounds across the fraction, including BaP (impaired learning and memory, decreased activity), naphthalene (clinical signs, including CNS depression), fluorene (impaired learning, clinical signs), and 1,2,4-triethylbenzene (impaired gait, muscular weakness) (U.S. EPA, 2017a, b; Peiffer et al., 2016; Tshala-Katumbay et al., 2006; U.S. EPA, 1998, 1990d). The lowest LOAELs (by compound) ranged from 2 to 114 mg/kg-day. Peripheral nerve damage was associated with observed impaired gait and muscular weakness in mice following exposure to 1,2,4-triethylbenzene at ≥129 mg/kg-day (Tshala-Katumbay et al., 2006). Impaired sensory and motor nerve conduction were also observed in rats following subchronic oral exposure to 1,2,4-triethylbenzene at ≥114 mg/kg-day (Gagnaire et al., 1993). However, no changes in peripheral nerve conduction or histology were observed in rats or mice similarly exposed to 1,3,5-triethylbenzene at doses up to 257 or 386 mg/kg-day, respectively (Tshala-Katumbay et al., 2006; Gagnaire et al., 1993). Histopathological findings in the peripheral nervous system (PNS) were not observed following subchronic oral exposure to fluoranthene or acenaphthene at doses of 500 and 700 mg/kg-day, respectively (U.S. EPA, 1990a, c). No changes in CNS histology were observed in animals following subchronic oral exposure to any tested compound (see Figure C-5). Decreased brain weight was observed following subchronic oral exposure to naphthalene at 133 mg/kg-day (U.S. EPA, 1998), but not following subchronic exposure to acenaphthene, anthracene, or fluorene (Peiffer et al., 2016; U.S. EPA, 1990a, b).

Figure C-5 Neurological Effects in Animals after Subchronic Oral Exposure to Aromatic High Carbon Range Compounds

No adverse neurological effects were observed in a limited number of chronic oral studies; therefore, chronic data are not included in Figure C-5. No changes in brain weight or histology were observed following chronic exposure to 1,1-biphenyl at doses up to 1,420 mg/kg-day, 1-methylnaphthalene at doses up to 144 mg/kg-day, or 2-methylnaphthalene at doses up to 114 mg/kg-day (U.S. EPA, 2013, 2011a, 2008, 2007a, 2003). No changes in PNS histology were observed following chronic exposure to 1,1-biphenyl at doses up to 1,420 mg/kg-day (U.S. EPA, 2013, 2011a). Neurological function was not evaluated in available chronic oral studies.

No data pertaining to neurological function were located following inhalation exposure to aromatic high carbon range compounds. No histopathological changes were observed in the brain following subchronic exposure to 2-methylnaphthalene at concentrations up to 8.9 mg/m^3^ or chronic exposure to naphthalene at concentrations up to 56 mg/m^3^ (Swiercz et al., 2011; ATSDR, 2005). An exposure-response graph to compare potencies across compounds was not included due to limited data.

### Summary of Potentially Relevant Evidence

Human evidence suggests that occupational exposure to PAH mixtures containing members of the aromatic high carbon range fraction, namely BaP, may alter neurobehavior, and occupational exposure to 1,1-biphenyl may damage nerve function. Available animal data show that oral exposure to compounds from across the aromatic high carbon range fraction (C10−C20) can alter neurobehavior in animals, including BaP, naphthalene, fluorene, and 1,2,4-triethylbenzene. Other effects reported in animal studies of one or more compounds include clinical signs of neurotoxicity, peripheral nerve damage, and decreased brain weight. Available data are too limited to assess potential neurological effects in animals following inhalation exposure. Considering human and animal evidence together, the available data indicate that some members of the aromatic high carbon range fraction induce neurological effects. BaP appears to be the most potent neurotoxicant, as the LOAEL for BaP is 1−2 orders of magnitude lower than the lowest LOAELs observed for other compounds see Figure C-5). However, there are a number of compounds within the aromatic high carbon range fraction that have not been evaluated for sensitive measures of neurological function, particularly 1,1-biphenyl. Additionally, no NOAEL values for neurofunctional endpoints were identified for BaP (however, there are BaP studies that did not report neurological effects at higher doses) or 1,2,4-triethylbenzene.

## HEPATIC EFFECTS

Hepatic effects are the critical endpoints for the subchronic p-RfD and chronic RfD for acenaphthene (U.S. EPA, 2011b) and the intermediate MRL for fluorene (ATSDR, 1995), and cocritical effects for the chronic RfD for fluoranthene (U.S. EPA, 1990c), and the subchronic provisional reference concentration (p-RfC) and chronic p-RfC for 1,1-biphenyl (U.S. EPA, 2011a). Critical hepatic effects of exposure included increased liver weight and hepatocellular hypertrophy for acenaphthene, increased liver weight for fluorene, and liver congestion and edema for 1,1-biphenyl. Human data pertaining to the hepatotoxicity of aromatic high carbon range fraction members are limited to a single case study of hepatotoxicity following occupational exposure to 1,1-biphenyl. As shown in Table 5, data on hepatic effects in animals were located for 11 members of the fraction. In general, the hepatic endpoints evaluated in the studies were liver weight and histology, with most studies also measuring clinical chemistry.

### Human Studies

A case report of a female worker exposed to 1,1-biphenyl indicated the presence of chronic hepatitis. The diagnosis was suggested by the presence of hepatomegaly and altered clinical chemistry findings and was confirmed by liver biopsy. Neutrophilic leukocytosis was also reported, suggesting an immunological or inflammatory response to liver injury. Serum enzymes returned to normal following cessation of exposure to 1,1-biphenyl (U.S. EPA, 2013).

### Animal Studies

Figures C-6 and C-7 show the effects of orally-administered aromatic high carbon range compounds on liver weight and histology, respectively. Data are available for 11 compounds, including compounds with carbon numbers C10−C20^4^. Hepatic alterations were observed with several compounds across the fraction, including naphthalene, 1,1-biphenyl, acenaphthene, fluorene, fluoranthene, and BaP (U.S. EPA, 2017a, b; Peiffer et al., 2016; U.S. EPA, 2013, 2012, 2011b, 1998, 1990c, d). The most sensitive and commonly observed effect following subchronic exposure was increased liver weight, with the lowest LOAELs (by compound) ranging from 7.1 to 2,989 mg/kg-day for all compounds listed above except naphthalene, which caused decreased liver weight at 133 mg/kg-day (see Figure C-6). No liver-weight effects were observed following subchronic exposure to anthracene at doses up to 1,000 mg/kg-day (U.S. EPA, 1990b). Liver-weight data for chronic oral exposure are limited to 1,1-biphenyl, 1-methylnaphthalene, and 2-methylnaphthalene. Increased liver weight was observed following chronic exposure to 1,1-biphenyl at 732 mg/kg-day (U.S. EPA, 2013), but not following chronic oral exposure to 1- or 2-methylnapthanene at doses up to 114−144 mg/kg-day (U.S. EPA, 2008, 2007a).

Figure C-6 Liver-Weight Effects in Animals after Oral Exposure to Aromatic High Carbon Range Compounds

Figure C-7 Liver Histology Effects in Animals after Oral Exposure to Aromatic High Carbon Range Compounds

Histopathological lesions were reported following oral exposure to BaP, fluoranthene, 1,1-biphenyl, and acenaphthene, but findings were generally proliferative effects associated with enzyme induction and were often inconsistent between studies for the same compound. Oval cell hyperplasia was reported in rats following exposure to BaP for 7 weeks at 64 mg/kg-day, but no effects were reported following 13-week exposure to BaP doses up to 100 mg/kg-day (U.S. EPA, 2017a, b). Following chronic exposure to BaP, clear cell foci were observed at ≥2 mg/kg-day (U.S. EPA, 2017a, b). For 1,1-biphenyl, degenerative changes and hepatic hyperplasia were reported in rats at doses ≥250 mg/kg-day for 8 or 56 weeks and hepatocellular hypertrophy and peroxisomal proliferation were observed in mice exposed at 2,989 mg/kg-day for 13 weeks, but no treatment-related liver lesions were observed after exposure for 104 weeks at doses up to 732 and 1,420 mg/kg-day in rats and mice, respectively (U.S. EPA, 2013). Hepatocellular hypertrophy was also reported following exposure to acenaphthene at ≥350 mg/kg-day for 13 weeks (U.S. EPA, 2011b). For fluoranthene, centrilobular pigmentation was reported in mice exposed at ≥250 mg/kg-day for 13 weeks, but not in similarly exposed rats at doses up to 1,500 mg/kg-day (U.S. EPA, 2012, 1990c). No histopathological hepatic lesions were noted following exposure to naphthalene, 1-methylnaphthalene, 2-methylnaphthalene, pyrene, fluorene, or anthracene (see Figure C-7).

Increased plasma aspartate aminotransferase (AST) and/or alanine aminotransferase (ALT) were observed in mice (but not rats) exposed to 1,1-biphenyl or fluoranthene at oral doses ≥414 mg/kg-day (U.S. EPA, 2013, 1990c), and increased total cholesterol was observed in mice exposed to acenaphthene at doses ≥350 mg/kg-day (U.S. EPA, 2011b). No significant alterations in hepatic serum chemistry were observed following subchronic exposure to BaP, naphthalene, pyrene, fluorene, or anthracene, or chronic exposure to 1-methylnaphthalene or 2-methylnaphthalene (U.S. EPA, 2017a, b, 2007a, b, 2003, 1998, 1990b, d, e). An exposure-response graph to compare potencies across compounds was not included due to lack of exposure-related effects in the majority of tested compounds.

Figure C-8 shows the effects of inhalation exposure to aromatic high carbon range compounds on hepatic endpoints. Data are available only for naphthalene, 2-methylnaphthalene, and 1,1-biphenyl, which represent compounds with carbon numbers C10−C12. Hepatic alterations were reported following subchronic exposure to 2-methylnaphthalene at ≥1.8 mg/m^3^ (decreased liver weight, altered serum chemistry, and bile duct hyperplasia) (Swiercz et al., 2011) and 1,1-biphenyl at ≥32.9 mg/m^3^, which was the lowest concentration tested (liver congestion and edema) (U.S. EPA, 2013). No histopathological hepatic findings were reported following chronic exposure to naphthalene at concentrations up to 28 and 56 mg/m^3^ in mice and rats, respectively (ATSDR, 2005; U.S. EPA, 1998).

Figure C-8 Liver and Renal Effects in Animals after Inhalation Exposure to Aromatic High Carbon Range Compounds

### Summary of Potentially Relevant Evidence

Human data are inadequate to assess potential hepatotoxic effects of aromatic high carbon range compounds. In animals, hepatic effects were primarily elevated liver weights following oral exposure to compounds from across the aromatic high carbon range fraction (C11−C20), with inconsistent evidence of histopathological damage for some compounds at higher doses (generally proliferative effects). A few compounds showed altered serum chemistry values at high oral doses. In aggregate, the data suggest that many aromatic high carbon range fraction compounds can produce increases in rodent liver weight following oral exposure, which is sometimes accompanied by serum chemistry and/or histological changes. No apparent pattern of sensitivity is observed based on number of carbons or ring structure. Available data are too limited to assess potential hepatic effects in animals following inhalation exposure.

## RENAL/BLADDER EFFECTS

Renal effects are the critical endpoints for the subchronic p-RfDs for pyrene and fluoranthene (U.S. EPA, 2012, 2007b) and the chronic RfDs for 1,1-biphenyl and pyrene (U.S. EPA, 2013, 1990e), and cocritical effects for the chronic RfD for fluoranthene (U.S. EPA, 1990c) and the subchronic p-RfC and chronic RfC for 1,1-biphenyl (U.S. EPA, 2011a). Critical renal effects of exposure included renal tubular nephropathy (pyrene, fluoranthene), renal mineralization (1,1-biphenyl), and decreased kidney weights (pyrene). No human studies examining renal or bladder effects of aromatic high carbon range compounds were identified in the sources reviewed. As shown in Table 5, data on renal and/or bladder effects in animals were located for 10 members of the fraction. In general, the renal endpoints evaluated in the studies were kidney weight and histology, with some studies also conducting urine and serum chemistry analyses. A few studies also evaluated histology of the bladder.

### Animal Studies

Figures C-9 and C-10 show the effects of orally-administered aromatic high carbon range compounds on renal and bladder endpoints following subchronic or chronic exposure, respectively. Data are available for 10 compounds, including compounds with carbon numbers C10−C20. Renal alterations were observed with several compounds across the fraction, including BaP, pyrene, fluorene, fluoranthene, and 1,1-biphenyl (U.S. EPA, 2017a, b, 2013, 2011a, b, 1990c, d, e). The most sensitive finding following subchronic exposure was altered kidney weight, with decreased kidney weight reported at BaP doses ≥21 mg/kg-day or pyrene doses ≥125 mg/kg-day and increased kidney weight reported at fluorene doses ≥250 mg/kg-day. Nephropathy was observed following subchronic exposure to pyrene at ≥125 mg/kg-day or fluoranthene at ≥250 mg/kg-day.

Figure C-9 Renal and Bladder Effects in Animals after Subchronic Oral Exposure to Aromatic High Carbon Range Compounds

Figure C-10 Renal Effects in Animals after Chronic Oral Exposure to Aromatic High Carbon Range Compounds

Additional renal and bladder effects were only observed following oral exposure to 1,1-biphenyl, including renal tubule degeneration and hyperplasia, focal calcification of the renal medulla, renal mineralization, tubule dilation and inflammation, hyperplastic and metaplastic lesions of the renal pelvis, desquamation of renal pelvis, papillary necrosis, urinary microcalculi, and bladder lesions (hyperplasia, papillomatosis, epithelial proliferation) at subchronic or chronic doses ≥250 mg/kg-day. Additionally, transitional cell hyperplasia in renal pelvis, pyelonephritis, kidney stones, and hemosiderin deposits were reported following chronic exposure to 1,1-biphenyl at LOAELs ranging from 128 to 732 mg/kg-day. Alterations in blood urea nitrogen (BUN) were sporadically reported following exposure to naphthalene, fluoranthene, and fluorene, and were not considered a clear indication of renal effects in the absence of additional renal effects (U.S. EPA, 2012, 1998, 1990d). No clearly adverse renal effects were observed following subchronic exposure to naphthalene, acenaphthene, or anthracene (see Figure C-9) (U.S. EPA, 1998, 1990a, b) or chronic oral exposure to 1- or 2-methylnapthalene (see Figure C-10) (U.S. EPA, 2008, 2007a, 2003).

Refer to Figure C-8 for the reported effects on renal endpoints following inhalation exposures to individual aromatic high carbon range compounds. Data are available only for naphthalene, 2-methylnaphthalene, and 1,1-biphenyl, which represent compounds with carbon numbers C10−C12. Decreased kidney weight was reported in rats exposed to 2-methylnaphthalene at ≥1.8 mg/m^3^ for 4 weeks (Swiercz et al., 2011) and kidney congestion and edema were observed in mice exposed to 1,1-biphenyl at ≥32.9 mg/m^3^ for 13 weeks (U.S. EPA, 2013). No exposure-related changes in renal histology were observed in rats or mice exposed to naphthalene at 56 or 28 mg/m^3^, respectively, for 2 years (ATSDR, 2005; U.S. EPA, 1998).

### Summary of Potentially Relevant Evidence

No human data are available. In animals, renal effects appear to be limited to organ weight changes and exacerbation of age-related nephropathy after exposure to high oral doses for compounds from across the aromatic high carbon range fraction (C11−C20), with the exception of 1,1-biphenyl (C12). Oral exposure to high doses of 1,1-biphenyl is associated with histopathological changes in both the kidney and bladder. Available data indicate that renal damage can also occur following inhalation exposure to 1,1-biphenyl. Data for other compounds are too limited to assess potential renal effects in animals following inhalation exposure. Taken together, the kidney and bladder appear to be a target of 1,1-biphenyl toxicity. Other high aromatic carbon range compounds may alter kidney weight and increase age-related nephropathy following oral exposure.

## RESPIRATORY

Pulmonary alveolar proteinosis is the critical endpoint for the subchronic p-RfD and chronic RfD for 2-methylnaphthalene, as well as the screening chronic p-RfD for 1-methylnaphthene (U.S. EPA, 2008, 2007a, 2003) (see Tables 6 and 7). Nasal lesions are the critical endpoint for the chronic RfC (see Table 8) and inhalation MRL^5^ for naphthalene (ATSDR, 2005; U.S. EPA, 1998). No human studies examining respiratory effects of aromatic high carbon range compounds were identified in the sources reviewed. As shown in Table 5, data on respiratory effects in animals were located for 10 members of the fraction. In general, the respiratory endpoints evaluated in the studies were lung weight and histology, with a few studies evaluating the entire respiratory tract (including nasal tissue).

### Animal Studies

Respiratory data following oral exposure are available for 10 compounds, including compounds with carbon numbers C10−C20. Respiratory findings were limited to pulmonary alveolar proteinosis alterations in mice following oral exposure to 1- or 2-methylnaphthalene at doses ≥50 or 72 mg/kg-day, respectively, for 81 weeks (no NOAEL was identified) (U.S. EPA, 2008, 2007a, 2003). However, pulmonary findings following oral exposure to 1- or 2-methylnapthalene were likely confounded by unquantified volatilization of these compounds from the feedstock (U.S. EPA, 2008, 2007a, 2003). No effect was observed on lung weight and/or histology following oral exposure to BaP, naphthalene, pyrene, fluoranthene, fluorene, 1,1-biphenyl, acenaphthene, or anthracene (U.S. EPA, 2017a, b, 2013, 2011a, 2007b, 1998, 1990a, b, c, d, e). Additionally, no histopathological changes were found in the upper respiratory tract following exposure to naphthalene or acenaphthene (U.S. EPA, 1998, 1990a). An exposure-response graph to compare potencies across compounds was not included due to lack of exposure-related effects in the majority of tested compounds.

Figure C-11 shows the effects of inhalation exposure to aromatic high carbon range compounds on respiratory endpoints. Data are available for naphthalene, 2-methylnaphthalene, and 1,1-biphenyl only, representing compounds with carbon numbers C10−C12. Respiratory effects were reported for all three compounds (U.S. EPA, 2013; Dodd et al., 2012; Swiercz et al., 2011; U.S. EPA, 2011b; ATSDR, 2005; U.S. EPA, 1998). The predominant respiratory effect associated with naphthalene exposure was nasal lesions following subchronic exposure to ≥0.9 mg/m^3^ in rats or chronic exposure to ≥9.3 mg/m^3^ (lowest concentration tested) in rats and mice. Lung inflammation was also observed in mice after chronic exposure to ≥9.3 mg/m^3^. Less severe nasal effects, characterized as nasal or upper respiratory irritation, were observed in rats and mice following subchronic exposure to 1,1-biphenyl at ≥1 mg/m^3^. Tracheal hyperplasia and inflammation, as well as lung congestion and edema, were observed in mice after subchronic exposure to higher concentrations of 1,1-biphenyl (≥32.9 mg/m^3^). However, no evidence of respiratory tract irritation was observed in rabbits after subchronic exposure to concentrations up to 60 mg/m^3^. Lung lesions (increased goblet cells, interstitial infiltration, hyperplasia of peribronchial tissue) were the primary respiratory effect in rats exposed to 2-methylnapthalene at ≥1.8 mg/m^3^ for 4 weeks (Swiercz et al., 2011).

Figure C-11 Respiratory Effects in Animals after Inhalation Exposure to Aromatic High Carbon Range Compounds

### Summary of Potentially Relevant Evidence

There were no relevant human data identified. Available animal data indicate that the respiratory tract is only a target of toxicity following oral exposure for methylated naphthalene compounds, 1- and 2-methylnaphthalene. For these two compounds, pulmonary alveolar proteinosis was observed at doses ≥72 or 50 mg/kg-day, respectively. Eight other compounds from across the fraction (C10−C20) did not show respiratory tract damage following oral exposure.

Inhalation data are limited but indicate that the lung is also a target of 2-methylnaphthalene following subchronic inhalation exposure; there are no data for 1-methylnapthalene. Subchronic inhalation studies also indicate that exposure to concentrations of naphthalene ≥0.9 mg/m^3^ results in damage to the nasal epithelium; concentrations of 1,1-biphenyl reportedly can result in irritation and irritation of the upper respiratory tract as well as lung congestion and edema. Taken together, data indicate that the respiratory tract (particularly nasal tissue) is a target of at least some aromatic high carbon range compounds following inhalation exposure; however, inhalation data are limited to compounds with carbon numbers ranging from C10 to C12 only. Other than the methylated naphthalene compounds, the respiratory system does not appear to be a target of oral toxicity for aromatic high carbon range compounds.

## GASTROINTESTINAL EFFECTS

No reference values for aromatic high carbon range compounds are based on gastrointestinal (GI) effects; however, the point of departure (POD) of 0.663 mg/kg-day based on GI effects reported for benzo[c]fluorene (which does not have any reference values) is lower than the currently available subchronic PODs for all fraction members except BaP (see Table 6). Available human studies are limited to reports of side effects in patients taking laxatives containing anthracene (U.S. EPA, 2009a). As shown in Table 5, data on GI effects in animals were located for 10 members of the fraction and a 21-PAH mixture. In general, the GI endpoints evaluated in the studies were GI histology, with a few studies evaluating stomach weight.

### Human Studies

Melanosis or hyperpigmentation of the lining of the colon and rectum was reported in patients taking anthracene-based laxatives for treatment of constipation (U.S. EPA, 2009a).

### Animal Studies

Figure C-12 shows the effects of orally-administered aromatic high carbon range compounds on GI endpoints. Data are available for nine compounds, including compounds with carbon numbers C10−C20. GI effects, specifically forestomach lesions, were observed following oral exposure to benzo[c]fluorene, BaP, and 1,1-biphenyl (U.S. EPA, 2017a, b, 2013; Weyand et al., 2004). Squamous hyperplasia was observed after subchronic exposure to benzo[c]fluorene at dietary doses ≥0.663 mg/kg-day (Weyand et al., 2004). Basal cell hyperplasia was observed after exposure to BaP at subchronic gavage doses ≥21 mg/kg-day and chronic gavage doses ≥2 mg/kg-day, but not after subchronic dietary doses up to 100 mg/kg-day (U.S. EPA, 2017a, b). For 1,1-biphenyl, epithelial hyperkeratinization was observed in rats after dietary exposure to doses ≥250 mg/kg-day for 8 or 56 weeks in one study, but not after chronic dietary exposure to doses up to 732 mg/kg-day in rats or 1,420 mg/kg-day in mice in three additional studies (U.S. EPA, 2013). No effects on GI histology were observed following subchronic gavage exposure to naphthalene, pyrene, fluoranthene, fluorene, acenaphthene, or anthracene (see Figure C-12).

Figure C-12 Gastrointestinal Effects in Animals after Oral Exposure to Aromatic High Carbon Range Compounds

Data for GI effects following oral exposure to mixtures are available from one study (not included in Figure C-12). In this study, squamous hyperplasia of the forestomach was noted in mice exposed to a 21-PAH mixture with or without benzo[c]fluorene in the diet for 37 weeks at doses of approximately 15−17 mg/kg-day (Weyand et al., 2004).

The potential effects of inhalation exposure to aromatic high carbon range compounds on the GI system were only evaluated for naphthalene and 2-methylnaphthalene (Swiercz et al., 2011; ATSDR, 2005). No changes were observed in GI histology following subchronic exposure to 2-methylnapthalene at concentrations up to 8.9 mg/m^2^ or chronic exposure to naphthalene at concentrations up to 56 mg/m^3^. An exposure-response graph to compare potencies across compounds was not included due to limited data.

### Summary of Potentially Relevant Evidence

Available human data are insufficient to assess potential GI effects following exposure to aromatic high carbon range compounds. Animal data report damage to the forestomach following exposure to three compounds from across the aromatic high carbon range fraction (C12−C20). Forestomach lesions were observed following subchronic exposure to benzo[c]fluorene at dietary doses ≥0.663 mg/kg-day (lowest dose tested, only available study), subchronic BaP at gavage doses ≥21 mg/kg-day, but not dietary doses up to 100 mg/kg-day, chronic BaP at gavage doses ≥2 mg/kg-day (no chronic dietary studies identified for BaP), and subchronic or chronic exposure to 1,1-biphenyl at doses ≥250 mg/kg-day in one of four available dietary studies (no gavage studies identified for 1,1-biphenyl). There was no evidence for GI lesions from six other compounds following subchronic exposure via gavage (C10−C16). Taken together, these data indicate that some aromatic high carbon range fraction compounds may cause hyperplastic lesions in the GI tract following oral exposure. Data are too limited to assess potential GI effects in animals following inhalation exposure.

## REPRODUCTIVE EFFECTS

No existing health reference values for aromatic high carbon range compounds are based on reproductive effects; however, available data from workers occupationally exposed to PAH mixtures indicates that the male and female reproductive systems may be a target of some members of this fraction. Human studies with data on PAH mixtures, often with a focus on BaP, include both occupational and smoking exposure studies. As shown in Table 5, data on reproductive endpoints in animals were located for 10 members of the fraction. However, data on reproductive function were only located for two members; the remaining studies evaluated reproductive organ weight and/or histology but did not assess reproductive function or capacity.

### Human Studies

Exposure to PAH mixtures has been associated with effects on male and female reproductive function (U.S. EPA, 2017a, b). Decreased sperm quality has been demonstrated in cigarette smokers, coke oven workers, and other men occupationally exposed to PAHs (U.S. EPA, 2017a, b). A study in coke oven workers reported oligospermia and an increase in the proportion of morphologically abnormal sperm (U.S. EPA, 2017a, b). Associations were also reported between exposure to PAHs (occupational exposure and smoking), PAH-adduct formation, and increased deoxyribonucleic acid (DNA) fragmentation in sperm (U.S. EPA, 2017a, b). A relationship was observed between the level of benzo[a]pyrene diol epoxide (BPDE)-DNA adducts in sperm and altered motility and morphology in patients at fertility clinics (U.S. EPA, 2017a, b). Higher levels of PAH-DNA adducts in sperm and higher urinary levels of PAHs were also associated with infertility (U.S. EPA, 2017a, b). The fertilizing capacity of sperm and the implantation rates of embryos were reduced in cigarette smokers (U.S. EPA, 2017a, b).

Reproductive effects related to ovulation, pregnancy, and spontaneous abortion have been reported in women who smoked cigarettes (U.S. EPA, 2017a, b). In utero exposure to maternal tobacco smoke may also affect the future fertility of female offspring (U.S. EPA, 2017a, b). Associations were reported between follicular fluid BaP levels and reduced conception and maternal blood BaP-DNA adduct levels and risk of miscarriage (U.S. EPA, 2017a, b). The level of BaP in placental tissue was significantly increased in women that experienced preterm birth (<36 weeks, n = 29) compared to women with full-term delivery (>36 weeks, n = 55) (Agarwal et al., 2017).

### Animal Studies

Oral and inhalation data on reproductive function are only available for a limited number of aromatic high carbon range fraction compounds. Therefore, exposure-response graphs were not generated to compare potencies across compounds for reproductive data.

Reproductive function studies following oral exposure were only available for two compounds: 1,1-biphenyl and BaP (U.S. EPA, 2017a, b, 2013, 2011a). Decreased fertility and litter size were observed in F_0_ and F_1_ parental rats exposed to 1,1-biphenyl in a multigenerational study at dietary doses of 887−1,006 mg/kg-day, but not ≤101 mg/kg-day. In one-generation studies in rats, no effects on reproductive performance were reported at doses up to 525 mg/kg-day; however, endpoints evaluated were very limited and considered insufficient for a full evaluation of reproductive performance. For BaP, male mice exposed to ≥1 mg/kg-day had low sperm counts, and sperm had decreased ability to penetrate ova in vitro; however, reproductive performance in vivo was not evaluated. Other reproductive studies reported sperm effects in male rats and mice following exposure to BaP at doses ≥0.01 mg/kg-day. Additional effects reported at ≥5 mg/kg-day include decreased testosterone levels, decreased testicular testosterone production, decreased sperm motility, increased percentage of abnormal sperm, and histopathological changes in the testes. In females, adverse effects were noted in rats (decreased ovary weight, decreased estradiol, decreased primordial follicles, and prolonged estrous cycle) and mice (increased cervical epithelial inflammation and hyperplasia) at doses ≥2.5 and 0.7 mg/kg-day, respectively.

Ten compounds from across the fraction (C10−C20) have data on reproductive organ weight and/or histology from subchronic or chronic assays that did not assess reproductive function or specialized reproductive endpoints (e.g., sperm parameters). One study reported significant decreases in ovary weight in mice exposed to acenaphthene at doses ≥175 mg/kg-day for 13 weeks (U.S. EPA, 2011b, 1990a). No exposure-related changes in reproductive organ weight were observed following oral exposure to naphthalene, fluoranthene, anthracene, 1,1-biphenyl, or BaP (U.S. EPA, 2013, 2011a; ATSDR, 2005; U.S. EPA, 1998, 1990b, c). No effects on reproductive organ histology were reported following subchronic or chronic exposure to 1-methylnaphthalene, 2-methylnaphthalene, pyrene, naphthalene, 1,1-biphenyl, fluorene, fluoranthene, acenaphthene, anthracene, or BaP (U.S. EPA, 2013, 2011a, b, 2008, 2007a, b; ATSDR, 2005; U.S. EPA, 2003, 1998, 1990a, b, c, d, e).

Inhalation data on the potential for altered reproductive function following exposure to aromatic high carbon range fraction compounds are limited to BaP (U.S. EPA, 2017a, b). Decreased ovulation rate was observed in female rats exposed to concentrations ≥0.008 mg/m^3^ for 2 weeks prior to mating (lowest concentration tested), with decreased ovarian weights observed at ≥0.013 mg/m^3^ and decreased pups/litter and embryo/fetal survival at 0.02 mg/m^3^. In another study, various effects were noted in male rats exposed to 0.013 mg/m^3^ (only concentration tested), including altered serum hormone levels (increased luteinizing hormone, decreased testosterone), decreased seminiferous tubule diameter and length, and sperm alterations (decreased motility and count, and increased percent of abnormal sperm).

Available inhalation data for other compounds in the fraction are limited to naphthalene and 2-methylnaphthalene (Swiercz et al., 2011; ATSDR, 2005). There was no evidence of histopathological changes in reproductive organs following chronic exposure to naphthalene at concentrations up to 56 mg/m^3^ and a lack of exposure-related changes in testes weight following subchronic exposure to 2-methylnaphthalene or naphthalene at concentrations up to 8.9 or 28 mg/m^3^, respectively.

### Summary of Potentially Relevant Evidence

Human data suggest that PAH mixtures, including compounds from the aromatic high carbon range fraction, may affect the male and female reproductive systems. Limited data from two compounds in animals, BaP and 1,1-biphenyl, support that fertility may be reduced following exposure to some compounds from the aromatic high carbon range fraction. However, the lack of data from other compounds regarding reproductive function precludes the ability to assess potential reproductive effects across the fraction in animals following oral or inhalation exposure.

## DEVELOPMENTAL EFFECTS

Developmental toxicity is the critical effect for the subchronic p-RfD for 1,1-biphenyl (U.S. EPA, 2011a) and the subchronic and chronic RfDs and RfCs for BaP^6^ (U.S. EPA, 2017a, b). Observed developmental effects include increased incidence of skeletal anomalies following oral exposure to 1,1-biphenyl, neurodevelopmental effects following oral exposure to BaP, and decreased embryo/fetal survival following inhalation exposure to BaP. Several human cohort studies evaluated potential associations between PAH exposure and altered offspring growth or neurodevelopment; many of these studies focused on BaP. As shown in Table 5, data on developmental endpoints in animals were located for five compounds and two mixtures from this fraction. Endpoints evaluated include standard teratology and offspring growth and survival studies, as well as special developmental studies (neurological, reproductive, and cardiac function).

### Human Studies

Several cohort studies have evaluated the potential association between exposure to PAH mixtures and offspring growth (U.S. EPA, 2017a, b). In Chinese women, elevated levels of benzo[a]pyrene diolepoxide-DNA (BPDE-DNA) adducts in cord blood were associated with reduced offspring weight at 18, 24, and 30 months of age, but not at birth (U.S. EPA, 2017a, b). In a U.S. cohort, reduced birth weight was associated with a doubling of cord blood BPDE-adducts combined with exposure to environmental tobacco smoke (no effect of either parameter alone) (U.S. EPA, 2017a, b). In a Spanish study, dietary BaP intake, determined by questionnaire, was associated with reduced birth weight, birth length, and small for gestational age (SGA) infants born to mothers with low vitamin C intake only (U.S. EPA, 2017a, b). Similar findings were reported in a larger cohort from Norway, which demonstrated an association between reported dietary BaP intake and reduced birth weight and birth length of offspring from all women, regardless of vitamin C intake. The magnitude of the association was increased for women consuming less than the recommended intake of vitamin C (U.S. EPA, 2017a, b). A case-control study of fetal death prior to 14 weeks of gestation in China showed a significant association between the level of maternal blood BPDE-DNA adducts and increased risk of fetal death; however, no association was observed between fetal tissue BPDE-DNA adduct levels and risk of fetal death (U.S. EPA, 2017a, b).

Several cohort studies have also evaluated the potential relationships between PAH exposure and neurodevelopmental effects occurring at birth and during childhood (U.S. EPA, 2017a, b). A birth cohort study from China showed evidence of associations between cord blood BPDE-adducts and reduced head circumference at birth, altered motor behavior and coordination at age 2 years, and reduced intelligence quotient scores at age 5 years (U.S. EPA, 2017a, b). Interactions with the effects of environmental tobacco smoke were noted. A birth cohort study conducted in New York City showed a similar association between cord blood BPDE-adducts and reduced head circumference at birth and also symptoms of anxiety/depression and attention problems at ages 6−7 years (U.S. EPA, 2017a, b). An magnetic resonance imaging (MRI) study of 8−12-year-old children in Spain showed an association between indoor and outdoor air levels of BaP and a decrease in the caudate nucleus volume of the basal ganglia (Mortamais et al., 2017). Neurobehavioral testing did not reveal significant changes in attention-deficit/hyperactivity disorder (ADHD) symptoms in this study.

### Animal Studies

Figures C-13 and C-14 show the effects of orally-administered aromatic high carbon range compounds on standard developmental endpoints (teratology and growth) and specialized developmental endpoints (neurodevelopment, reproductive development, cardiac function), respectively. Data for these endpoints are available for four compounds, including compounds with carbon numbers C10−C20. Developmental effects were reported for all tested compounds. Effects associated with gestational exposure to benzo[b]fluoranthene included impaired male reproductive development at ≥0.002 mg/kg-day (lowest dose tested) and decreased pup weight at 0.02 mg/kg-day (Kim et al., 2011). Effects associated with exposure to BaP included neurodevelopmental effects (altered behavior, impaired learning, altered cortical activity) following gestational exposure to doses ≥0.2 mg/kg-day, altered cardiovascular function in offspring following gestational exposure to doses ≥0.6 mg/kg-day, decreased pup body weight following early postnatal exposure to doses ≥2 mg/kg-day or gestational doses ≥10 mg/kg-day, and altered reproductive development and decreased F_1_ fertility in males and females at ≥10 mg/kg-day (U.S. EPA, 2017a, b).

Figure C-13 Teratology and Offspring Growth Effects in Animals after Oral Exposure to Aromatic High Carbon Range Compounds

Figure C-14 Specialized Developmental Endpoints in Animals after Oral Exposure to Aromatic High Carbon Range Compounds

Effects associated with naphthalene and 1,1-biphenyl occurred at much higher doses; however, no special developmental studies (e.g., neurodevelopmental) were identified. A decrease in the number of live pups was observed in mice following gestational exposure to naphthalene at 300 mg/kg-day; similar effects were not seen in similarly exposed rats or rabbits (U.S. EPA, 1998). For 1,1-biphenyl, effects included increased incidence of missing or unossified sternebrae after gestational exposure to doses ≥500 mg/kg-day and decreased F_1_, F_2_, and F_3_ pup weights in a multigenerational study with exposure to 1,006 mg/kg-day (U.S. EPA, 2013).

Neurodevelopmental data are also available in rats following exposure to a mixture of 16 PAHs during gestation or gestation and lactation, which contained 2.5% BaP (Crepeaux et al., 2014, 2013, 2012); this study is not included in Figure C-14. Complete mixture composition is presented in Appendix B, Table B-2. Adverse effects (delayed eye or ear opening, impaired neuromuscular coordination, increased activity, increased anxiety-like behavior) were observed at mixture doses ≥0.002 mg/kg-day, which delivered a BaP dose of 0.00005 mg/kg-day.

The potential effects of inhalation exposure to aromatic high carbon range compounds on the developing organism were only evaluated for BaP and a 9-PAH mixture (predominantly pyrene, composition shown in Appendix B, Table B-3); therefore, an exposure-response graph comparing potencies across compounds was not included. Adverse developmental effects were noted in all three available BaP gestational studies, including decreased embryo survival, decreased number of implantations, and decreased pups/litter at concentrations ≥0.0042 mg/m^3^ (U.S. EPA, 2017a, b). Electrophysiological changes in the hippocampus were also observed in offspring following maternal exposure to BaP at 0.02 mg/m^3^ during gestation (only tested concentration). Standard developmental endpoints were not evaluated for the 9-PAH mixture; instead, endpoints in offspring included adiposity and immune function in offspring (Yan et al., 2014; Chu et al., 2013). Observed findings included increased airway reactivity in ovalbumin-sensitized mice following early postnatal exposure (Chu et al., 2013) and elevated body weight and fat mass in F_1_ and F_2_ offspring (Yan et al., 2014). The study authors reported a nominal exposure concentration of 7.29 ng/m^3^ (7.29 × 10^−6^ mg/m^3^) for the mixture exposure level. However, the measured concentration of pyrene (as a marker of mixture exposure) in the exposure chamber averaged 23 ng/m^3^ (range 7.38−40 ng/m^3^); the control exposure chamber averaged 3 ng/m^3^ pyrene, with a range of 0−9 ng/m^3^. Based on the reported proportion of pyrene in the mixture (52.59%), the 23 ng/m^3^ average for pyrene corresponds to an approximate average mixture concentration of 44 ng/m^3^ (4.4 × 10^−5^ mg/m^3^). This exposure concentration is well below the developmental LOAEL for BaP (0.0042 mg/m^3^).

### Summary of Potentially Relevant Evidence

Human data suggest that PAH mixtures, including compounds from the aromatic high carbon range fraction, may adversely affect offspring growth and neurodevelopment. Limited data from three compounds in animals, benzo[b]fluoranthene, BaP, and 1,1-biphenyl, show that offspring growth may be affected following exposure to some compounds from the aromatic high carbon range fraction. Data on neurodevelopment in animals are limited to BaP (and mixtures containing BaP) but indicate that adverse neurological effects can occur following early life exposure at low doses. Limited animal data from benzo[b]fluoranthene, BaP, and mixtures also indicate that the developing reproductive, immune, and cardiovascular systems may be targets of toxicity for this fraction. However, the lack of developmental data from other compounds, particularly specialized developmental data, precludes a comparison of developmental effects and potencies across the fraction.

## OTHER EFFECTS

### Human Studies

Cataract formation was reported in 8 of 21 workers exposed to naphthalene for >5 years in a dye-producing plant. Bilateral cataracts were also reported in a case study of a pharmacist who ingested 5 g of naphthalene (ATSDR, 2005; U.S. EPA, 1998).

Studies in coke oven workers have suggested that PAHs may impair the immune system (U.S. EPA, 2017a, b). Affected immune parameters include reductions in serum immunoglobulin M (IgM) and/or immunoglobulin A (IgA) titers, elevated immunoglobulin G (IgG) and immunoglobulin E (IgE) levels, and reduced T-cell mitogenic and proliferative responses (U.S. EPA, 2017a, b). Elevated levels of the urinary metabolites of naphthalene, phenanthrene, and pyrene were associated with hypersensitivity in 5- and 9-year-old children, as measured by serum levels of cockroach-specific IgE (an indicator of hypersensitivity) (U.S. EPA, 2017a, b). Blood phenanthrene levels were elevated in children (1−14 years old) diagnosed with bronchial asthma in a hospital-based, case-control study in India (Suresh et al., 2009).

Occupational exposure to PAH mixtures and cigarette smoke have been associated with cardiovascular effects including atherosclerosis and ischemic heart disease (U.S. EPA, 2017a, b). Mortality from cardiovascular disease and risk of ischemic heart disease were elevated in workers at a coke oven plant and an aluminum smelter, respectively (U.S. EPA, 2017a, b). Urinary metabolites of phenanthrene, BaP, and benzo[a]anthracene were positively correlated with diastolic blood pressure in chimney sweeps in Sweden (Alhamdow et al., 2017). Serum markers of cardiovascular disease risk were also elevated in these workers (increased homocysteine, cholesterol, and high-density lipoproteins). Two cross-sectional studies of the U.S. population used National Health and Nutrition Examination Survey (NHANES) data to evaluate potential associations between urinary PAH metabolites and risk factors of cardiovascular disease (Ranjbar et al., 2015; Clark et al., 2012). Clark et al. (2012) did not demonstrate a relationship between urinary concentrations of naphthalene, fluorene, phenanthrene, or pyrene metabolites (NHANES 2001−2004 data set) and serum biomarkers of cardiovascular disease (fibrinogen, homocysteine, and WBC count) (Clark et al., 2012). Ranjbar et al. (2015) showed positive associations between the urinary concentrations of some PAH metabolites (NHANES 2001−2008 data set) and hypertension (naphthalene and phenanthrene), obesity (phenanthrene), metabolic syndrome risk factors including cholesterol, triglycerides, blood pressure, and glucose abnormalities (naphthalene, fluorene, and phenanthrene), and type 2 diabetes (naphthalene, phenanthrene, and pyrene).

### Animal Studies

As observed in human studies, cataract formation is a well-documented effect in laboratory animals following exposure to high oral doses of naphthalene, generally at doses ≥1,000 mg/kg-day (U.S. EPA, 1998).

The immune system has been identified as a potential target of BaP toxicity in animals exposed by multiple routes (U.S. EPA, 2017a, b). Changes in thymus weight and histology and alterations in the spleen (e.g., decreased B cell percentages) have been reported at oral doses ≥7.1 mg/kg-day, with decreased immune responses in a modified local lymph node assay at 13 mg/kg-day. Immune function was also impaired following subcutaneous doses ≥5 mg/kg-day. Developmental immunotoxicity studies reported impaired immune responses following in utero exposure via intraperitoneal (i.p.) injection. Inhalation data for immune endpoints were not available for BaP. Data regarding immune function for other members of the fraction are limited to naphthalene, which did not show any exposure-related changes in a battery of immunological assays following oral exposure to doses up to 133 mg/kg-day for 90 days (U.S. EPA, 1998).

Several studies have reported oral transplacental carcinogenesis following gestational exposure to dibenzo[def,p]chrysene in mice (Madeen et al., 2016; Benninghoff and Williams, 2013; Shorey et al., 2013; Shorey et al., 2012; Castro et al., 2009; Castro et al., 2008c; Castro et al., 2008a; Castro et al., 2008b). In these studies, dibenzo[def,p]chrysene was administered during gestation, resulting in the induction of fatal T-cell acute lymphoblastic leukemia/lymphoma in offspring; pups typically died from this or other tumors within a year. Those that survived frequently developed lung, liver, or ovarian tumors. Because of the fatal nature of the neoplasia in offspring, and the fact that they result from gestational exposure, these studies can be considered to straddle the line between cancer and developmental toxicity outcomes. None of the studies identified a dose that did not influence offspring tumor incidence, with doses ≥1 mg/kg administered once yielding increased lung tumor incidences. Pup mortality due to T-cell acute lymphoblastic leukemia/lymphoma was increased at doses ≥6.5 mg/kg.

4 Based on the U.S. EPA PPRTV for BeP, no short-term, subchronic, chronic, or reproductive and developmental toxicity studies of BeP in humans or animals exposed by oral or inhalation routes were adequate for the derivation of a toxicity value. The toxicity values for BeP are based on a read-across approach that used BaP as a surrogate.

5 The ATSDR chronic inhalation MRL for naphthalene is based on the 105-week study in Fischer 344 rats (NTP, 2000). The study reported inflammation of the nose (including, olfactory epithelium, atypical hyperplasia, atrophy, degeneration); nasal respiratory epithelium (including hyperplasia, squamous metaplasia, and degeneration); and Bowman’s glands hyperplasia observed in the 10 PPM dose group. The chronic MRL of 0.0007 ppm was based on a human equivalent concentration LOAEL of 0.2 ppm, which was divided by an uncertainty factor of 300 (10 for using the LOAEL, 3 for extrapolating from rodents to humans using an interspecies dosimetric adjustment, and 10 for human interindividual variability).

6 The chronic RfD for BaP is based on a developmental exposure; therefore, it is also applicable to subchronic exposures. Subchronic and chronic screening p-RfD values for BeP were also based on developmental effects because BaP was used as an analogue.