# APPENDIX B COMPOSITION OF MIXTURES RELEVANT TO THE AROMATIC HIGH CARBON RANGE FRACTION

Table B-1 lists information on the 21-PAH mixture composition for the Weyand et al. (2004) oral carcinogenicity study. The composition of the 16-PAH mixture in the Crepeaux et al. (2014, 2013, 2012) oral neurodevelopmental toxicity studies is shown in Table B-2. Information on the composition of the 9-PAH mixture in the Yan et al. (2014) and Chu et al. (2013) inhalation developmental studies is provided in Table B-3.

Table B-1 Composition of PAH Mixture Tested in Dietary Carcinogenesis Study (Limited Noncancer Endpoints)^a^

Chemical | C | EC | Level in Diet (mg/kg food) | PAH Mix | | PAH Mix with Benzo[c]fluorene
Chemical | C | EC | Level in Diet (mg/kg food) | Dose (μg/mouse/d) | mg/Mouse over 260 d | Dose (μg/mouse/d) | mg/Mouse over 260 d
Indan | 9 | 9.74 | 1.23 | 2.6 | 0.7 | 2.8 | 0.7
Naphthalene | 10 | 11.57 | 80.8 | 170 | 43.7 | 186 | 48.7
2-Methylnaphthalene | 11 | 12.72 | 26.8 | 56.2 | 14.5 | 61.5 | 16.1
1-Methylnaphthalene | 11 | 12.77 | 14.2 | 29.7 | 7.7 | 32.5 | 8.5
Acenaphthylene | 12 | 14.82 | 14.3 | 30 | 7.7 | 32.8 | 8.6
Acenaphthene | 12 | 14.76 | 3.18 | 6.7 | 1.7 | 7.3 | 1.9
Dibenzofuran | 12 | 13.24 | 4.53 | 9.5 | 2.4 | 10.4 | 2.7
Fluorene | 13 | 15.68 | 11.9 | 25 | 6.5 | 27.4 | 7.2
Phenanthrene | 14 | 18.37 | 25.3 | 53 | 13.7 | 58.1 | 15.2
Anthracene | 14 | 18.43 | 7.25 | 15.2 | 3.9 | 16.7 | 4.4
Fluoranthene | 16 | 21.11 | 15.9 | 33.4 | 8.6 | 36.6 | 9.6
Pyrene | 16 | 22.45 | 18.1 | 37.9 | 9.8 | 41.5 | 10.9
Benz[a]anthracene | 18 | 25.27 | 8.35 | 17.5 | 4.5 | 19.2 | 5
Chrysene | 18 | 26.13 | 7.4 | 15.5 | 4 | 17 | 4.5
Benzo[b]fluoranthene | 20 | 25.04 | 7.23 | 15.2 | 3.9 | 16.6 | 4.4
Benzo[k]fluoranthene | 20 | 28.70 | 2.53 | 5.3 | 1.4 | 5.8 | 1.5
Benzo[a]pyrene | 20 | 29.95 | 6.9 | 14.5 | 3.7 | 15.9 | 4.2
Indeno[1,2,3-cd]pyrene | 22 | 32.62 | 4.98 | 10.4 | 2.7 | 11.4 | 3
Dibenz[a,h]anthracene | 22 | 32.45 | 0.93 | 1.9 | 0.5 | 2.1 | 0.6
Benzo[ghi]perylene | 22 | 30.37 | 5.73 | 12 | 3.1 | 13.2 | 3.5
Benzo[c]fluorene | 17 | 21.45 | 5.6 | – | – | 13.6 | 3.6
Sum | | | | 561.5 | 144.7 | 628.4 | 164.8

a Weyand et al. (2004).

C = carbon; EC = equivalent carbon; PAH = polycyclic aromatic hydrocarbon.

Table B-2 Composition of 16-PAH Mixture Tested in Oral Neurodevelopmental Studies^a^

CASRN | Name | Rings | C | EC | Percent in 16-PAH Mixture (%) | PAH Dose in Low-Dose Mixture (mg/kg-d) | PAH Dose in High-Dose Mixture (mg/kg-d)
91-20-3 | Naphthalene | 1 | 10 | 11.57 | 17 | 0.00034 | 0.034
208-96-8 | Acenaphthylene | 2 | 12 | 14.82 | 1.5 | 0.00003 | 0.003
83-32-9 | Acenaphthene | 2 | 12 | 14.76 | 10 | 0.0002 | 0.02
86-73-7 | Fluorene | 2 | 13 | 15.68 | 2.5 | 0.00005 | 0.005
85-01-8 | Phenanthrene | 3 | 14 | 18.37 | 25 | 0.0005 | 0.05
120-12-7 | Anthracene | 3 | 14 | 18.43 | 3.5 | 0.00007 | 0.007
129-00-0 | Pyrene | 4 | 16 | 22.45 | 8.5 | 0.00017 | 0.017
206-44-0 | Fluoranthene | 3 | 16 | 21.11 | 11.5 | 0.00023 | 0.023
218-01-9 | Chrysene | 4 | 18 | 26.13 | 4 | 0.00008 | 0.008
56-55-3 | Benzo[a]anthracene | 4 | 18 | 25.27 | 2 | 0.00004 | 0.004
205-99-2 | Benzo[b]fluoranthene | 4 | 20 | 25.04 | 2.5 | 0.00005 | 0.005
207-08-9 | Benzo[k]fluoranthene | 4 | 20 | 28.70 | 2 | 0.00004 | 0.004
50-32-8 | Benzo[a]pyrene | 4 | 20 | 29.95 | 2.5 | 0.00005 | 0.005
193-39-5 | Indeno(1,2,3-c,d)pyrene | 5 | 22 | 32.62 | 6 | 0.00012 | 0.012
53-70-3 | Dibenzo[a,h]anthracene | 5 | 22 | 32.45 | 0.5 | 0.00001 | 0.001
191-24-2 | Benzo[ghi]perylene | 6 | 22 | 30.37 | 1 | 0.00002 | 0.002
Sum/mixture dose | | | | | | 0.002 | 0.2

a Crepeaux et al. (2014, 2013, 2012).

C = carbon; EC = equivalent carbon; PAH = polycyclic aromatic hydrocarbon.

Table B-3 Composition of PAH Aerosol Mixture Tested in Inhalation Developmental Studies^a^

CASRN | Name | Rings | C | EC | Percent in Mixture (%) | Mean Concentration (ng/m^3^) | Mean Concentration (mg/m^3^)
129-00-0 | Pyrene | 4 | 16 | 20.8 | 3.99 | 0.27 | 0.00027
218-01-9 | Chrysene | 4 | 18 | 26.13 | 5.13 | 0.42 | 0.00042
56-55-3 | Benzo[a]anthracene | 4 | 18 | 26.37 | 7.62 | 0.59 | 0.00059
205-99-2 | Benzo[b]fluoranthene | 4 | 20 | 30.14 | 1.79 | 0.15 | 0.00015
207-08-9 | Benzo[k]fluoranthene | 4 | 20 | 30.14 | 13.02 | 1.12 | 0.00112
50-32-8 | Benzo[a]pyrene | 4 | 20 | 31.34 | 4.82 | 0.35 | 0.00035
193-39-5 | Indeno(1,2,3-c,d)pyrene | 5 | 22 | 33.51 | 0.89 | 0.06 | 0.00006
53-70-3 | Dibenzo[a,h]anthracene | 5 | 22 | 33.92 | 7.42 | 0.64 | 0.00064
191-24-2 | Benzo(ghi)perylene | 6 | 22 | 34 | 54.59 | 3.69 | 0.00369
Sum/mixture concentration | | | | | | 7.29 | 0.00729

a Yan et al. (2014); Chu et al. (2013).

C = carbon; EC = equivalent carbon; PAH = polycyclic aromatic hydrocarbon.