# APPENDIX A LITERATURE SEARCH AND SCREENING

Literature searches were conducted in February 2018 and updated in August 2021 for studies relevant to the derivation of provisional toxicity values for 44 constituents of the aromatic high carbon range fraction of total petroleum hydrocarbons (TPHs). This included the U.S. Environmental Protection Agency (U.S. EPA) initial list of 41 relevant chemicals and 6 additional chemicals identified in the search of the Provisional Peer-Reviewed Toxicity Value (PPRTV) database (total 47) less benzo[a]pyrene (BaP) and naphthalene that had chronic and subchronic health risk values on the Integrated Risk Information System (IRIS) and benzo[e]pyrene (BeP) that had PPRTV health risk values (see Table 3). Database searches for PubMed and Web of Science were conducted by an information scientist. Initial searches were date limited from 2007 to 2018. The records were stored using the U.S. EPA’s Health and Environmental Research Online (HERO) database of scientific literature. The PubMed database was searched using the HERO interface. The updated search was conducted similarly using the same search strings in PubMed and Web of Science from February 2018 through August 2021. There was an additional search of Agency for Toxic Substances and Disease Registry (ATSDR) and U.S. EPA documents for health risk values for fraction members.

The results of the PubMed searches were screened (title and abstract) for relevance using the Population, Exposure, Comparator, and Outcome (PECO) criteria outline in Table A-1. Full-text screening for relevance to hazard identification was performed using the refined PECO criteria shown in Table A-2.

Table A-1 PECO Criteria for Screening of TPH Constituent Literature Search Results

PECO Element | Inclusion Criteria
Population | Humans (any population) or laboratory mammals (any life stage)
Exposure | Human: Exposure to the subject material alone or as the primary component of a mixture, known or presumed to occur by oral, inhalation, and/or dermal routes.; Animal: In vivo, exposure to the subject material alone, by oral or inhalation (including instillation) routes, for all durations of exposures (durations <28 days will be captured as supporting information), including any duration during gestation. Other routes of exposure will be captured as supporting information.
Comparison | Human: Includes any comparison/referent group (no exposure, lower exposure).; Animal: Includes concurrent negative (untreated, sham-treated, or vehicle) control.
Outcomes | Assesses any cancer or noncancer endpoint in any tissue, organ, or physiological system.

PECO = Population, Exposure, Comparator, and Outcome; TPH = total petroleum hydrocarbon.

Table A-2 PECO Criteria for Relevance to Hazard Identification

PECO Element | Inclusion Criteria
Population | Humans (any population) or laboratory mammals (any life stage)
Exposure | Human: Exposure to the subject material alone or as the primary component of a mixture, known or presumed to occur by oral or inhalation routes.; Animal: In vivo, exposure to the subject material alone, by oral or inhalation routes, for durations ≥28 days^a^ or any duration during gestation.
Comparison | Human: Includes any comparison/referent group (no exposure, lower exposure).; Animal: Includes concurrent negative (untreated, sham-treated, or vehicle) control.
Outcomes | Assesses any noncancer health outcome in any tissue, organ, or physiological system.

a It is noted that the PPRTV program often considers studies of shorter duration. However, given the database and the described relative potency of benzo[a]pyrene (which was selected as the indicator chemical), it is unlikely that a more sensitive endpoint than those captured in studies ≥28 days in duration will be identified in data from acute studies.

PECO = Population, Exposure, Comparator, and Outcome; PPRTV = Provisional Peer-Reviewed Toxicity Value.