# COMMONLY USED ABBREVIATIONS AND ACRONYMS

α2u-g: alpha 2u-globulin
ACGIH: American Conference of Governmental Industrial Hygienists
AIC: Akaike’s information criterion
ALD: approximate lethal dosage
ALT: alanine aminotransferase
AR: androgen receptor
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
BMC: benchmark concentration
BMCL: benchmark concentration lower confidence limit
BMD: benchmark dose
BMDL: benchmark dose lower confidence limit
BMDS: Benchmark Dose Software
BMR: benchmark response
BUN: blood urea nitrogen
BW: body weight
C#: number of carbon atoms contained in a molecule
CA: chromosomal aberration
CAS: Chemical Abstracts Service
CASRN: Chemical Abstracts Service registry number
CBI: covalent binding index
CHO: Chinese hamster ovary (cell line cells)
CL: confidence limit
CNS: central nervous system
CPHEA: Center for Public Health and Environmental Assessment
CPN: chronic progressive nephropathy
CYP450: cytochrome P450
DAF: dosimetric adjustment factor
DEN: diethylnitrosamine
DMSO: dimethylsulfoxide
DNA: deoxyribonucleic acid
EC: equivalent carbon
EPA: Environmental Protection Agency
ER: estrogen receptor
FDA: Food and Drug Administration
FEV_1_: forced expiratory volume of 1 second
GD: gestation day
GDH: glutamate dehydrogenase
GGT: γ-glutamyl transferase
GSH: glutathione
GST: glutathione-S-transferase
Hb/g-A: animal blood-gas partition coefficient
Hb/g-H: human blood-gas partition coefficient
HEC: human equivalent concentration
HED: human equivalent dose
i.p.: intraperitoneal
IRIS: Integrated Risk Information System
IVF: in vitro fertilization
LC_50_: median lethal concentration
LD_50_: median lethal dose
LOAEL: lowest-observed-adverse-effect level
MN: micronuclei
MNPCE: micronucleated polychromatic erythrocyte
MOA: mode of action
MTD: maximum tolerated dose
NAG: N-acetyl-β-D-glucosaminidase
NCI: National Cancer Institute
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
NZW: New Zealand White (rabbit breed)
OCT: ornithine carbamoyl transferase
ORD: Office of Research and Development
PBPK: physiologically based pharmacokinetic
PCNA: proliferating cell nuclear antigen
PND: postnatal day
POD: point of departure
POD_ADJ_: duration-adjusted POD
QSAR: quantitative structure-activity relationship
RBC: red blood cell
RDS: replicative DNA synthesis
RfC: inhalation reference concentration
RfD: oral reference dose
RGDR: regional gas dose ratio
RNA: ribonucleic acid
SAR: structure-activity relationship
SCE: sister chromatid exchange
SD: standard deviation
SDH: sorbitol dehydrogenase
SE: standard error
SGOT: serum glutamic oxaloacetic transaminase, also known as AST
SGPT: serum glutamic pyruvic transaminase, also known as ALT
SSD: systemic scleroderma
TCA: trichloroacetic acid
TCE: trichloroethylene
TWA: time-weighted average
UF: uncertainty factor
UF_A_: interspecies uncertainty factor
UF_C_: composite uncertainty factor
UF_D_: database uncertainty factor
UF_H_: intraspecies uncertainty factor
UF_L_: LOAEL-to-NOAEL uncertainty factor
UF_S_: subchronic-to-chronic uncertainty factor
U.S.: United States of America
WBC: white blood cell

Abbreviations and acronyms not listed on this page are defined upon first use in the PPRTV document.