# 6 DERIVATION OF PROVISIONAL VALUES

## 6.1 DERIVATION OF ORAL REFERENCE DOSES

Subchronic provisional RfDs (p-RfDs) are available for five constituents of the fraction. The critical effects for these subchronic p-RfDs are peripheral nervous system effects (n-hexane), body-weight changes (methylcyclopentane), hepatic changes (2,4,4-trimethylpentene, cyclohexene), and forestomach lesions (n-heptane based on read-across analogue analysis). There are three available chronic RfDs for constituent compounds (cyclohexene, n-heptane, and 2,4,4-trimethylpentene); all of these are based on the same studies and points of departure (PODs) as the corresponding subchronic RfDs. Table 6 summarizes the subchronic and chronic RfDs for constituent compounds and mixtures, with PODs, uncertainty factors, critical effects, and associated confidence descriptors.

Table 6 Available RfD Values for Aliphatic Low Carbon Range Fraction (C5–C8 [EC5–EC8])^a^

Indicator Chemical or Components | POD (mg/kg-d) | POD Type | UFc | UF Components | RfD or p-RfD (mg/kg-d) | Confidence in RfD or p-RfD | Critical Effect(s) | Species, Mode, and Duration | Reference
Subchronic
n-Hexane; (C6 [EC6]) | 785 | LOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_L_ | 0.3 | Low | Reductions in motor nerve conduction velocity (nervous) | Rat, gavage, 8 wk | U.S. EPA (2009a); Ono et al. (1981)
Methylcyclopentane; (C6 [EC6.27]) | 357 | NOAEL | 1,000 | UF_A_, UF_D_, UF_H_ | 0.4 | Low | Reduced body weight (body weight) | Rat, gavage, 5 d/wk for 4 wk | U.S. EPA (2009d); Halder et al. (1985)
Cyclohexene; (C6 [EC6.74]) | 4.81 | BMDL_1SD_ (HED) | 100 | UF_A_, UF_D_, UF_H_ | 0.05 | Low | Increased total serum bilirubin (hepatic) | Rat, gavage, one-generation | MHLW (2001) as cited in U.S. EPA (2012b)
n-Heptane; (C7 [EC7]) | 3.13 | BMDL_10_ | 1,000 | UF_A_, UF_D_, UF_H_ | 0.003 ^b^ | Low | Based on n-nonane as analogue; forestomach histopathology (GI) | Mouse, gavage, 13 wk | Dodd et al. (2003) as cited in U.S. EPA (2016)
2,4,4-Trimethylpentene; (C8 [EC6.8]) | 41.5 | BMDL_10_ (HED) | 300 | UF_A_, UF_D_, UF_H_ | 0.1 ^b^ | Low | Increased relative liver weight (hepatic) | Rat, gavage, one-generation | Huntingdon Life Sciences (1997a) as cited in U.S. EPA (2015)
Chronic
Cyclohexene; (C6 [EC6.74]) | 4.81 | BMDL_1SD_ (HED) | 1,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.005 | Low | Increased total serum bilirubin (hepatic) | Rat, gavage, one-generation | MHLW (2001) as cited in U.S. EPA (2012b)
n-Heptane; (C7 [EC7]) | 3.13 | BMDL_10_ | 10,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.0003 ^b^ | Low | Based on n-nonane as analogue; forestomach histopathology (GI) | Mouse, gavage, 13 wk | Dodd et al. (2003) as cited in U.S. EPA (2016)
2,4,4-Trimethylpentene; (C8 [EC6.8]) | 41.5 | BMDL_10_ (HED) | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.01 ^b^ | Low | Increased relative liver weight (hepatic) | Rat, gavage, one-generation | Huntingdon Life Sciences (1997a) as cited in U.S. EPA (2015)

a Bolded row shows the compound and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

BMDL = benchmark dose lower confidence limit; BMDL_10_ = 10% benchmark dose lower confidence limit; C = carbon; EC = equivalent carbon; GI = gastrointestinal; HED = human equivalent dose; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure; PPRTV = Provisional Peer-Reviewed Toxicity Value; p-RfD = provisional reference dose; RfD = oral reference dose; SD = standard deviation; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

As suggested by the disparity in critical effects and values of RfDs for fraction members and discussed in Appendix C, the available oral toxicity data for aliphatic low carbon range compounds do not demonstrate significant consistency across fraction members in terms of toxicological effects or potencies. Thus, there is no basis to identify an indicator chemical or mixture that is representative of the effects and potency of the fraction as a whole. Therefore, the most potent component compounds and mixtures were considered as the basis for indicator chemical selection, as outlined in the methodology (see Section 2.3).

### 6.1.1 Oral Noncancer Assessment Using the Indicator Chemical Method for the Aliphatic Low Carbon Range Fraction

If available analytical chemistry data do not identify concentrations of individual chemicals composing this fraction, the subchronic and chronic p-RfDs (0.05 and 0.005 mg/kg-day, respectively) for cyclohexene are recommended as the indicator chemical for the aliphatic low carbon range fraction (U.S. EPA, 2012b). The p-RfDs for cyclohexene are based on hepatic toxicity, and available data generally support the liver as a target of aliphatic low carbon compounds. Although the RfDs for cyclohexene are not the lowest available, the subchronic and chronic p-RfD values for n-heptane (0.003 and 0.0003 mg/kg-day, respectively) are not recommended, for the following three reasons. First, the n-heptane p-RfDs are screening values based on a read-across analysis and therefore carry additional uncertainty associated with the analogue approach. Second, the analogue upon which the values are based (n-nonane) is outside (C9 [EC9]) the carbon range of the fraction. Third, the chronic p-RfD for n-heptane is highly uncertain, derived with a composite uncertainty factor (UF_C_) of 10,000. Evaluation of available data as discussed in Appendix C suggests that use of the cyclohexene p-RfD values is reasonably anticipated to be protective for effects associated with exposures to other constituents of the fraction. Users of the indicator chemical method should understand that there could be more uncertainty associated with the application of this toxicity value to the aliphatic low carbon range fraction than for its derivation in U.S. EPA (2012b).

The cyclohexene PPRTV assessment cited Ministry of Health, Labour, and Welfare (MHLW, 2001a, b as cited in U.S. EPA, 2012b) as the principal studies for the subchronic and chronic p-RfDs:

MHLW (2001a) conducted a subchronic oral toxicity study that also examined reproductive and developmental effects that will be discussed separately (MHLW, 2001b). This study appears to be proprietary (may have been part of a Japanese toxicity assessment conducted by MHLW) and is in Japanese. OECD SIDS (2002) peer-reviewed and summarized the study (cited as MHLW, 2002) and EPA subsequently had the document translated. The internal and external peer reviewers of this PPRTV document also concurred that the MHLW (2001a) study was suitable for deriving a provisional toxicity value. This study was conducted as a combined repeated dose toxicity study with reproduction/developmental toxicity screening according to OECD test guideline 422 and was stated by OECD to be GLP compliant (no GLP statement was provided in the study report).

Crj:CD(SD)IGS rats (12 animals/sex/treatment group) were administered 0, 50, 150, or 500 mg/kg-day of cyclohexene (98.6% pure) in corn oil via gavage. Dose formulations were tested for concentration and stability. Males were dosed for 48 days and females for 43−53 days beginning 14 days before mating, throughout the mating and gestational period, to Day 4 of lactation. Animals were observed for clinical signs of toxicity daily. Body weight and food consumption were measured weekly and at necropsy. Urinalysis was conducted on 5 males/treatment group at 43−48 days of treatment. At sacrifice (on Day 49 for males and 5 days after delivery for females), blood was collected for hematology and clinical chemistry in all animals. The brain, liver, kidney, spleen, adrenal glands, thymus, testis, and epididymis were weighed. Tissues and organs were examined histologically in at least the control and high-dose group. Statistical analyses performed included Bartlett’s test for homogeneity of variance, Dunnett’s multiple comparison test (if equal variance), and Steel’s test for unequal variances. The χ2 and Fisher’s exact probability tests were also used where appropriate.

Salivation was observed at 150 (for about 5 minutes in 3/12 males and 2/12 females) and 500 mg/kg-day (all animals for 30−60 minutes in males and 6 hours in females). Lacrimation was observed in 2/12 males at 500 mg/kg-day and females at ≥150 mg/kg-day (1/12 for each dose group). There were some small—but statistically significant—hematological changes at 500 mg/kg-day. Increased were the number of reticulocytes and bilirubin in males and prothrombin time and total bile acids in females. Decreased was the level of APTT in males. There were no treatment-related significant changes in body weight, or food consumption, in either sex or in the urinalysis findings for males (females not measured). There was a dose-dependent decrease in triglyceride in males (see Table B.1). Even though triglyceride in the 500 mg/kg-day group males was 43% lower than in the controls, the results were not statistically significant nor was this effect noted in the females. There was an increase in total bilirubin in both sexes; reanalysis of the data indicates that there are statistically significant increases at all doses in males and in high-dose females. Total bile acid was increased by >10% in all dose groups. However, the results were highly variable and not dose dependent. Only the 150-mg/kg-day males and the 50- and 500-mg/kg-day females showed statistically significant changes above the controls. High-dose males had a statistically significant increase in relative kidney weight that was not accompanied by any histopathological changes and did not reach 1SD (standard deviation) above the control (see Table B.2). OECD SIDS (2002) reported a NOAEL of 50 mg/kg-day for the repeated dose toxicity portion of the test based on transient salivation observed in both sexes at 150 mg/kg-day. Transient salivation is not considered sufficiently adverse to identify as a critical effect. Although the bile acid increase was not dose dependent and was variable, the data taken together may indicate bile duct blockage. Bile duct blockage is also consistent with the statistically significant increase in alkaline phosphatase in rats noted by Laham (1976) following inhalation exposure. Based on the statistically significant increase in total bile acid in females and total bilirubin in males at the lowest dose, no NOAEL can be determined, and the LOAEL is 50 mg/kg-day.

The selected critical effect of total bilirubin in male rats was BMD modeled. The resultant benchmark dose lower confidence limit with one standard deviation (BMDL_1SD_) of 19.71 mg/kg-day was subsequently converted to a human equivalent dose (HED) of 4.81 mg/kg-day (see Table 6). As reported in U.S. EPA (2012b), confidence in the principal study was medium. Although the study was described as being conducted according to OECD Test Guideline (TG) 422 and was subsequently translated by U.S. EPA, the OECD (2002) SIDS report is a secondary data source. As reported in U.S. EPA (2012b), confidence in the database was low, because only one oral repeated-dose study was available. Therefore, confidence in the subchronic and chronic p-RfDs was also low.

### 6.1.2 Alternative Oral Noncancer Assessment Using the Hazard Index Method for the Aliphatic Low Carbon Range Fraction

If the available analytical chemistry data quantify the concentrations of n-hexane, methylcyclopentane, cyclohexene, n-heptane, or 2,4,4-trimethylpentene separately from the remainder of the low carbon fraction, it is recommended that HQs for the individual chemicals with analytical data be calculated and an HI for the mixture be developed using the calculated HQs.

For subchronic oral exposures, the following subchronic p-RfDs can be used as the denominator in the HQ equations: n-hexane (0.3 mg/kg-day), methylcyclopentane (0.4 mg/kg-day), cyclohexene (0.05 mg/kg-day), n-heptane (0.003 mg/kg-day), and 2,4,4-trimethylpentene (0.1 mg/kg-day). In this alternative approach, the subchronic p-RfD (0.05 mg/kg-day) for cyclohexene is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually (see Table 6).

For chronic oral exposures, the following chronic p-RfDs can be used in the denominator of the HQ equations: cyclohexene (0.005 mg/kg-day), n-heptane (0.0003 mg/kg-day), and 2,4,4-trimethylpentene (0.01 mg/kg-day). In this alternative approach, the chronic p-RfD (0.005 mg/kg-day) for cyclohexene is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually (see Table 6).

## 6.2 DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

The available subchronic and chronic RfC values, with PODs, uncertainty factors, critical effects, and confidence descriptors are presented in Table 7. As shown in the table, there are subchronic and chronic RfCs or provisional RfCs (p-RfCs) for one mixture (commercial hexane) and four individual compounds (n-pentane, n-hexane, cyclohexane, and n-heptane) relevant to the aliphatic low carbon range fraction. In addition, there is a chronic p-RfC for cyclohexene. The critical effects for the subchronic RfCs include peripheral nervous system injury (n-hexane), diminished hearing sensitivity (n-heptane), decreased body weight and nervous system effects (commercial hexane), and developmental toxicity (decreased pup weight; cyclohexane). The critical effects for the chronic RfCs include peripheral nervous system injury (n-hexane), diminished hearing sensitivity (n-heptane), liver pathology (spongiosis hepatis; cyclohexene), nasal lesions (hyperplasia; commercial hexane), and developmental toxicity (decreased pup weight; cyclohexane).

Table 7 Available RfC Values for Aliphatic Low Carbon Range Fraction (C5–C8 [EC5–EC8])^a^

Indicator Chemical or Components | POD (mg/m^3^) | POD Type (all are HECs) | UFc | UF Components | RfC or p-RfC (mg/m^3^) | Confidence in RfC or p-RfC | Critical Effect(s) | Species, Mode, and Duration | Reference
Subchronic
n-Pentane; (C5 [EC5]) | 3,658 | NOAEL | 300 | UF_A_, UF_D_, UF_H_ | 10 | Low | No treatment-related effects | Rat, 6 h/d, 5 d/wk for 13 wk | McKee and Frank (1998) as cited in U.S. EPA (2009e)
Commercial hexane; (C6) | 804 | NOAEL | 30 | UF_A_, UF_H_ | 27 | Medium | Abnormal gait; decreased body weight; mild atrophy of sciatic and/or tibial nerve and skeletal muscle (nervous and body weight) | Rat, 22 h/d, 7 d/wk for 6 mo | IRDC (1992) as cited in U.S. EPA (2009b)
n-Hexane; (C6 [EC6]) | 215 | BMCL_1SD_ | 100 | UF_A_, UF_D_, UF_H_ | 2 | Low | Peripheral neuropathy (nervous) | Rat, 12 h/d, 7 d/wk for 16 wk | Huang (1989) as cited in U.S. EPA (2009a)
Cyclohexane; (C6 [EC6.58]) | 1,822 | BMCL_1SD_ | 100 | UF_A_, UF_D_, UF_H_ | 18 | Moderate | Reduced pup weight (developmental) | Rat, 6 h/d, 5 d/wk, two-generation | Kreckmann (2000) and Dupont HLR (1997a), both as cited in U.S. EPA (2010)
n-Heptane; (C7 [EC7]) | 1,170 | BMCL_1SD_ | 300 | UF_A_, UF_D_, UF_H_ | 4 | Low | Loss of hearing sensitivity (nervous) | Rat, 6 h/d, 7 d/wk for 28 d | Simonsen and Lund (1995) as cited in U.S. EPA (2016)
Chronic
n-Pentane; (C5 [EC5]) | 3,658 | NOAEL | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 1 | Low | No treatment-related effects | Rat, 6 h/d, 5 d/wk for 13 wk | McKee et al. (1998) as cited in U.S. EPA (2009e)
Commercial hexane; (C6) | 17.59 | BMCL_10_ | 30 | UF_A_, UF_H_ | 0.6 | Medium | Nasal epithelial cell hyperplasia (respiratory) | Rat, 6 h/d, 5 d/wk for 2 yr | Daughtrey et al. (1999) and Biodynamics (1993), both as cited in U.S. EPA (2009b)
n-Hexane; (C6 [EC6]) | 215 | BMCL_1SD_ | 300 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.7 | Medium | Peripheral neuropathy (nervous) | Rat, 12 h/d, 7 d/wk for 16 wk | Huang et al. (1989) as cited in U.S. EPA (2005)
Cyclohexane; (C6 [EC6.58]) | 1,822 | BMCL_1SD_ | 300 | UF_A_, UF_D_, UF_H_ | 6 | Low-moderate | Reduced pup weight (developmental) | Rat, 6 h/d, 5 d/wk, two-generation | Kreckmann et al. (2000) and DuPont HLR (1997a) as cited in U.S. EPA (2010)
Cyclohexene; (C6 [EC6.74]) | 360 | NOAEL | 300 | UF_A_, UF_D_, UF_H_ | 1 ^b^ | Low | Spongiosis hepatis (hepatic) | Rat, 6 h/d, 5 d/wk for 104 wk | MHLW (2003) as cited in U.S. EPA (2012b)
n-Heptane; (C7 [EC7]) | 1,170 | BMCL_1SD_ | 3,000 | UF_A_, UF_D_, UF_H_, UF_S_ | 0.4 | Low | Loss of hearing sensitivity (nervous) | Rat, 6 h/d, 7 d/wk for 28 d | Simonsen and Lund (1995) as cited in U.S. EPA (2016)

a Bolded row shows the compounds and toxicity value selected as the indicator chemical for the fraction if analytical chemistry data do not identify concentrations of individual chemicals composing this fraction.

b Toxicity values are provisional values obtained from an existing PPRTV assessment. Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening provisional values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

BMCL = benchmark concentration lower confidence limit; BMCL_10_ = 10% benchmark concentration lower confidence limit; C = carbon; EC = equivalent carbon; HEC = human equivalent concentration; NOAEL = no-observed-adverse-effect level; POD = point of departure; PPRTV = Provisional Peer-Reviewed Toxicity Value; p-RfC = provisional reference concentration; RfC = inhalation reference concentration; SD = standard deviation; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_C_ = composite uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_S_ = subchronic-to-chronic uncertainty factor.

As suggested by the disparity in critical effects and values of RfCs for fraction members and discussed in Appendix C, the available inhalation toxicity data for aliphatic low carbon range compounds do not demonstrate significant consistency across fraction members in terms of toxicological effects or potencies. There is no basis to identify an indicator chemical or mixture that is representative of the effects and potency of the fraction as a whole. Therefore, the most potent component compounds and mixtures were considered as the basis for indicator chemical selection, as outlined in the methodology (see Section 2.3).

### 6.2.1 Inhalation Noncancer Assessment Using the Indicator Chemical Method for the Aliphatic Low Carbon Range Fraction

If available analytical chemistry data do not identify concentrations of individual chemicals composing this fraction, the lowest subchronic and chronic p-RfCs among the compounds in this fraction, for n-hexane and n-heptane, respectively [(U.S. EPA, 2016, 2009a); see Table 7] are recommended as indicator chemicals for the aliphatic low carbon range fraction. Use of these values is anticipated to be protective for exposure to other constituents based on available information (see Appendix C). However, users of the indicator chemical method should understand that there could be more uncertainty associated with the application of this toxicity value to the aliphatic low carbon range fraction than for its derivation in (U.S. EPA, 2016, 2009a).

The U.S. EPA (2009a) n-hexane PPRTV assessment cited Huang et al. (1989) Huang et al. (1989) as cited in U.S. EPA (2009a) as the principal study for the subchronic p-RfC:

Male Wistar rats (eight/group) were exposed to 0, 500, 1200, or 3000 ppm (0, 1762, 4230, 10,574 mg/m3) n-hexane (>99% pure) for 12 hours/day, 7 days/week for 16 weeks (Huang et al., 1989). The authors measured motor nerve conduction velocity (MCV) in the tail nerve along with body weight before exposure and after 4, 8, 12, and 16 weeks of exposure to n-hexane. One animal from each group was sacrificed at 16 weeks exposure for histopathological evaluation of the nerve fibers in the tail. In addition, Huang et al. (1989) measured the levels of neuron-specific enolase and beta-S-100. These nervous system-specific proteins are a family of calcium binding proteins that are involved in processes such as cell-to-cell communication, cell growth, intracellular signal transduction, and development and maintenance of the central nervous system. A dose-dependent, statistically significant reduction in body weight gain was observed in the mid- (at 12 weeks) and high-dose (at 8 weeks) rats. Additionally, there were some neurological deficits in mid- and high-dose rats, including a reduction in grip strength and a comparative slowness of motion from week 12 of exposure. However, no hindlimb paralysis was observed by the termination of the experiment. Rats exposed to the mid and high doses of n-hexane showed a reduction in MCV. This reduction was statistically significant during weeks 8–16 of the exposure period compared with controls. Increased incidence of paranodal swellings, along with some evidence of demyelination and remyelination, was present in the peripheral nerves at both mid and high doses. However, these histopathological findings were more severe in the high dose group. Among biochemical changes, there were dose-dependent reductions in nervous system specific proteins, particularly the beta-S-100 proteins from tail nerve fibers, which were significantly reduced by approximately 75% at all dose levels. The neurophysiological deficits and histopathological effects that were evident in mid- and high-dose rats indicate a NOAEL of 500 ppm.

The Huang et al. (1989) study as cited in U.S. EPA (2009a) provided adequate dose-response data for BMD modeling with an estimated POD (benchmark concentration lower confidence limit [BMCL] human equivalent concentration [HEC]) of 215 mg/m^3^ (see Table 7). As reported in U.S. EPA (2009a), confidence in the principal study was medium. The study used a low, but acceptable, number of animals per group (8/sex); data enabled identification of NOAEL and LOAEL values for neurological effects. As reported in U.S. EPA (2009a), confidence in the database was low due to the lack of a multigenerational developmental and reproductive toxicity study. Therefore, confidence in the subchronic p-RfC was also low.

The U.S. EPA (2009a) n-heptane PPRTV assessment cited Simonsen and Lund (1995) as the principal study for the chronic p-RfC:

In this neurotoxicity study, groups of male Long-Evans rats (9−10/group) were placed in whole-body chambers and exposed to n-heptane (99.5% pure) vapors at reported mean concentrations of 0, 801 ± 79, or 4,006 ± 242 ppm, 6 hours/day for 28 days. The study was aimed at evaluating potential effects of n-heptane on the central auditory system, given that exposure to organic solvents has been associated with hearing loss in rats and humans (Simonsen and Lund, 1995). Feed and water were available ad libitum except during exposure periods. Six weeks prior to exposure, screw electrodes were mounted in the skull of the rats for measurement of auditory brainstem responses. The amplitudes and latencies of Components Ia and IV of the auditory brainstem responses elicited at frequencies 4, 8, 16, or 32 kHz and intensities 25−95 dB were measured in anaesthetized rats 2 months after cessation of exposure using both implanted electrodes and needle electrodes. Body weight was monitored throughout the study. No other systemic endpoints were assessed.

Body-weight gain during the first 2 weeks postexposure was significantly decreased by 53% in the 4,006-ppm group. However, body weights were similar in all three exposure groups during the course of treatment. The peak amplitudes of the Ia and IV components of the auditory brainstem responses were reduced in rats exposed to 4,006 ppm at all frequencies and intensities, compared with control (0-ppm treatment group), but not at 801 ppm. Statistically significant reductions were reported for Component IV, most prominently at higher frequencies and intensities (see Table B-4). Decreases in amplitude of Component Ia displayed a similar pattern to IV; however statistical analyses for this component were not provided. No exposure-related changes were observed in the latencies or interpeak latencies of the Ia and IV components. The reduction in the peak amplitudes corresponded to an approximate 10-dB increase in the auditory threshold. The difference in auditory threshold between the control and the 4,006-ppm group was observed at all frequencies, although statistical significance was only reached at 8 and 16 kHz (see Table B-5 from n-heptane PPRTV assessment, data have been digitally extracted using GrabIt! Software).

A NOAEL of 801 ppm and a LOAEL of 4,006 ppm is identified for abnormal auditory brainstem responses and increased auditory threshold that suggest a loss of hearing sensitivity in rats. Concentrations of 801 and 4,006 ppm are converted to human equivalent concentrations (HECs) of 821 and 4,105 mg/m3 for extrarespiratory effects by treating n-heptane as a Category 3 gas (generally water insoluble and unreactive in the extrathoracic or tracheobronchial regions) and using the following equation (U.S. EPA, 1994a): HECEXRESP = (ppm × molecular weight [MW] ÷ 24.45) × (hours per day exposed ÷ 24) × (days per week exposed ÷ 7) × ratio of blood-gas partition coefficient (animal:human). For n-heptane, the blood-air partition coefficient for rats is greater than that for humans (Gargas et al., 1989); thus, a default ratio of 1 is applied (U.S. EPA, 1994a).

BMD analyses were performed to model central auditory effects (all frequencies) in rats exposed to n-heptane. Only data sets at frequencies of 16 and 32 Hz provided an adequate fit. The lowest benchmark concentration lower confidence limit with one standard deviation (BMCL_1SD_) (HEC) of 1,170 mg/m^3^ was selected as the POD (see Table 7). As reported in U.S. EPA (2016), confidence in the study was medium. Although the study was peer-reviewed, used adequate methodology, and provided identification of NOAEL and LOAEL values for auditory effects, it was a short-term (28 days) study in male rats only, and a limited number of endpoints were evaluated. As reported in U.S. EPA (2016), confidence in the database was low, because no developmental or multigeneration studies were available; the chronic study did not provide organ-weight data or perform thorough histopathological examinations. Therefore, confidence in the chronic p-RfC was also low.

### 6.2.2 Alternative Inhalation Noncancer Assessment Using the Hazard Index Method for the Aliphatic Low Carbon Range Fraction

If the available analytical chemistry data quantify the concentrations of n-pentane, n-hexane, cyclohexane, cyclohexene, or n-heptane separately from the remainder of the low carbon fraction, it is recommended that HQs for the individual chemicals with analytical data be calculated and an HI for the mixture be developed using the calculated HQs.

For subchronic inhalation exposures, the following subchronic p-RfCs can be used as the denominator in the HQ equations: n-pentane (10 mg/m^3^), n-hexane (2 mg/m^3^), cyclohexane (18 mg/m^3^), and n-heptane (4 mg/m^3^). In this alternative approach, the subchronic p-RfC for n-hexane (2 mg/m^3^) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually.

For chronic inhalation exposures, the following chronic p-RfCs can be used as the denominator in the HQ equations: n-pentane (1 mg/m^3^), n-hexane (0.7 mg/m^3^), cyclohexane (6 mg/m^3^), cyclohexene (1 mg/m^3^), and n-heptane (0.4 mg/m^3^). In this alternative approach, the chronic p-RfC for n-heptane (0.4 mg/m^3^) is recommended for use with the remainder of the fraction, including any other fraction members analyzed individually.

## 6.3 SUMMARY OF NONCANCER PROVISIONAL REFERENCE VALUES

Table 8 summarizes the noncancer health references values for indicator chemicals used when available analytical data and exposure estimates are limited to either air concentrations of, or oral exposure rates associated with, the whole fraction. When analytical results, air concentrations, or exposure rate measures for individual compounds with reference values are available, then the hazards associated with these compounds can be assessed separately, using the HI approach and reference values reported in Tables 6 and 7.

Table 8 Summary of Noncancer Reference Estimates for Indicator Chemicals for Aliphatic Low Carbon Range (C5–C8 [EC5–EC8]) Fraction of Total Petroleum Hydrocarbons

Toxicity Type (units); Indicator Chemical | Species/Sex | Critical Effect | p-Reference Value | POD Method | POD (HED/HEC) | UFc | Reference
Subchronic p-RfD (mg/kg-d); cyclohexene | Rat/M | Hepatotoxicity (increased total serum bilirubin) | 5 × 10^−2^ | BMDL_1SD_ | 4.81 | 100 | MHLW (2001) as cited in U.S. EPA (2012b)
Chronic p-RfD (mg/kg-d); cyclohexene | Rat/M | Hepatotoxicity (increased total serum bilirubin) | 5 × 10^−3^ | BMDL_1SD_ | 4.81 | 1,000 | MHLW (2001) as cited in U.S. EPA (2012b)
Subchronic p-RfC (mg/m^3^); n-hexane | Rat/M | Neurotoxicity (peripheral neuropathy) | 2 × 10^0^ | BMCL_1SD_ | 215 | 100 | Huang et al. (1989) as cited in U.S. EPA (2009a)
Chronic p-RfC (mg/m^3^); n-heptane | Rat/M | Neurotoxicity (loss of hearing sensitivity) | 4 × 10^−1^ | BMCL_1SD_ | 1,170 | 3,000 | Simonsen and Lund (1995) as cited in U.S. EPA (2016)

BMDL = benchmark dose lower confidence limit; C = carbon; EC = equivalent carbon; HEC = human equivalent concentration; HED = human equivalent dose; M = male; POD = point of departure; p-RfC = provisional reference concentration; p-RfD = provisional reference dose; SD = standard deviation; UF_C_ = composite uncertainty factor.

## 6.4 CANCER WEIGHT-OF-EVIDENCE DESCRIPTOR

The inhalation cancer assessment outcomes for mixtures and individual components of the aliphatic low carbon range fraction that have existing assessments are shown in Table 9. The only component of the fraction for which there is information available to adequately assess carcinogenic potential is commercial hexane. The PPRTV assessment for commercial hexane (U.S. EPA, 2009b) describes the WOE as follows:

Under the 2005 Guidelines for Carcinogen Risk Assessment (U.S. EPA, 2005b), there is “Suggestive Evidence for [the] Carcinogenic Potential” of commercial hexane in humans. There are no data on carcinogenicity of commercial hexane in humans. A 2-year carcinogenicity bioassay in mice and rats exposed to commercial hexane showed an increased incidence of liver tumors (combined hepatocellular adenomas and carcinomas) in female mice (Daughtrey et al., 1999; Biodynamics, 1993a, b). No increase in liver tumor incidence was observed in treated male mice or in either sex of F344 rats exposed to commercial hexane under the same conditions. The study authors also identified a statistically significant increase in the incidence of pituitary tumors in female mice. Available data on the genotoxicity of commercial hexane are limited; no gene reversion or chromosomal aberrations in mammalian cells and no chromosomal aberrations in the bone marrow of rats exposed in vivo were observed in the only tests conducted.

Table 9 Available Cancer WOE Descriptors for Aliphatic Low Carbon Range Fraction (C5–C8 [EC5–EC8])

Compound or Mixture | Cancer WOE Descriptor | Source
n-Pentane (C5 [EC5]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2009e)
Commercial hexane (C6 [EC NA]) | “Suggestive Evidence of Carcinogenic Potential” | U.S. EPA (2009b)
n-Hexane (C6 [EC6]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2005)
Methylcyclopentane (C6 [EC6.27]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2009d)
Cyclohexane (C6 [EC6.59]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2010)
Cyclohexene (C6 [EC6.74]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2012b)
2,2,4-Trimethylpentane (C8 [EC6.98]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2007)
n-Heptane (C7 [EC7]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2016)
Methylcyclohexane (C7 [EC7.22]) | “Inadequate Information to Assess Carcinogenic Potential” | U.S. EPA (2013)

C = carbon; EC = equivalent carbon; NA = not applicable; WOE = weight of evidence.

While data on genotoxicity testing of compounds and mixtures in the aliphatic low carbon range fraction are limited, available information suggests little to no genotoxic potential (see Section 5).

## 6.5 DERIVATION OF PROVISIONAL CANCER RISK ESTIMATES

None of the mixtures or constituents in this fraction had an oral slope factor (OSF) from IRIS, PPRTVs, HEAST, MassDEP, or TPHCWG. Thus, a provisional OSF (p-OSF) is not derived for the fraction. The only available inhalation unit risk (IUR) value for members of the aliphatic low carbon range fraction is a screening p-IUR for commercial hexane (U.S. EPA, 2009b). In the absence of data to support a clear ‘best’ surrogate for the mixture, the most health-protective value will be adopted to protect against the carcinogenicity of components of the mixture. The provisional IUR (p-IUR) of 2 × 10^−4^ (per mg/m^3^) for combined pituitary adenomas and adenocarcinomas in female mice exposed to commercial hexane is selected to assess inhalation carcinogenicity for this fraction (see Table 10).

Table 10 Summary of Cancer Risk Estimates for Aliphatic Low Carbon Range (C5–C8 [EC5–EC8]) Fraction of Total Petroleum Hydrocarbons

Toxicity Type (units); Indicator Chemical | Species/Sex | Tumor Type | Cancer Risk Estimate | Reference
p-OSF (mg/kg-d)^−1^ | NDr
p-IUR (mg/m^3^)^−1^; commercial hexane | Mouse/F | Pituitary adenomas or adenocarcinomas | 2 × 10^−4^ | Daughtrey et al. (1989) and Biodynamics (1993), both as cited in U.S. EPA (2009b)

C = carbon; EC = equivalent carbon; F = female; NDr = not determined; p-IUR = provisional inhalation unit risk; p-OSF = provisional oral slope factor.