# 5 MECHANISTIC CONSIDERATIONS AND GENOTOXICITY

Of the health effects induced by aliphatic low carbon range compounds, mechanistic information is available to inform mode of action only for peripheral nervous system effects. Peripheral neuropathy after exposure to n-hexane has been previously established to result from production of a γ-diketone metabolite, 2,5-hexanedione (U.S. EPA, 2005). Metabolism of n-hexane yields relatively high levels of the diketone (U.S. EPA, 2005). Available metabolic data (see Table 5) show only two compounds (n-hexane and n-heptane) for which γ-diketone formation has been demonstrated; however, few data are available to assess whether other compounds in the fraction may be metabolized to γ-diketone intermediates. Compared to n-hexane, metabolism of n-heptane yields much smaller amounts of γ-diketone (U.S. EPA, 2016).

Among the compounds and mixtures with any genotoxicity data summarized in comprehensive U.S. EPA toxicity assessments (commercial hexane, n-pentane, methylcyclopentane, cyclohexane, cyclohexene, n-hexane, n-heptane, 2,2,4-trimethylpentane, and 2,4,4-trimethylpentene), genotoxicity data were largely negative. Positive findings were reported for n-hexane (minimal mutagenic activity in Saccharomyces cerevisiae and slightly increased incidences of chromosomal aberrations [CAs] in rat bone marrow after in vivo exposure) (U.S. EPA, 2005).