# 4 TOXICOKINETIC CONSIDERATIONS

The available toxicokinetic information on compounds and mixtures in the aliphatic low carbon range fraction has been reviewed extensively (Mckee et al., 2015; Baxter, 2012; Carreón and Herrick, 2012). In general, these compounds and mixtures are absorbed by both inhalation and oral routes and are distributed widely in the body with some preference for adipose tissue and kidney. Metabolism of alkane compounds is predominantly via hydroxylation to alcohols, which are further hydroxylated or dehydrogenated to hydroxy and/or ketone derivatives. Alkenes are metabolized via epoxide intermediates to glycols. Elimination of aliphatic low carbon range fractions occurs via exhaled air (as carbon dioxide [CO_2_]) and urine.

Oral absorption of compounds in the aliphatic low carbon range fraction is high. Estimates of the absorbed fraction of orally-administered doses are 86% for 2,2,4-trimethylpentane (U.S. EPA, 2007) and 90% for cyclohexane (Mckee et al., 2015). Oral absorption of aliphatic hydrocarbons was inversely proportional to molecular weight and independent of structure (linear, branched, or alicyclic) in a rat study examining a wide range of aliphatic compounds [reviewed by Mckee et al. (2015)]. Based on conclusions from Mckee et al. (2015), oral absorption of the remaining compounds in the aliphatic low carbon range fraction is expected to be in the range of 80−90%.

Absorption of inhaled aliphatic low carbon range hydrocarbons is high and increases with molecular weight and boiling point (Mckee et al., 2015), as suggested by existing blood-gas partition coefficients. For example, relatively little n-pentane is absorbed into the bloodstream after inhalation exposure, because it partitions preferentially into the gas phase (Perbellini et al., 1985). Blood-gas partition coefficients reported in comprehensive toxicity assessments for fraction members, or in publications cited by these assessments (Gargas et al., 1989; Perbellini et al., 1985) are shown in Table 4. As the table indicates, partition coefficients in humans are higher for compounds with higher EC (which is linearly correlated to boiling point) and molecular weight.

Table 4 Blood-Gas Partition Coefficients for Aliphatic Low Carbon Compounds

Compound | C | EC | Molecular Weight (g/mol) | Human | Rat
n-Pentane | 5 | 5 | 72.15 | 0.38^a^ | 1.48^b^
2,2-Dimethylbutane | 6 | 5.68 | 86.18 | 0.26^a^ | –
2-Methylpentane | 6 | 5.72 | 86.18 | 0.41^a^ | –
3-Methylpentane | 6 | 5.85 | 86.18 | 0.43^a^ | –
n-Hexane | 6 | 6 | 86.18 | 0.80^a^ | 2.29^c^
Methylcyclopentane | 6 | 6.27 | 84.16 | 0.86^a^ | –
Cyclohexane | 6 | 6.58 | 84.16 | 1.4^c^ | 1.39^c^
3-Methylhexane | 7 | 6.76 | 100.21 | 1.3^a^ | –
2,2,4-Trimethylpentane | 8 | 6.98 | 114.23 | 1.60^c^ | 1.77^c^
n-Heptane | 7 | 7 | 100.21 | 2.85^c^ | 4.75^c^

a Perbellini et al. (1985).

b Meulenberg and Vijverberg (2000) as cited in U.S. EPA (2009e).

c Gargas et al. (1989).

C = carbon; EC = equivalent carbon.

Compounds in the aliphatic low carbon range are widely distributed in the body after inhalation or oral exposure. In rats exposed by inhalation, n-pentane was distributed primarily to liver, kidney, and small intestine (Mckee et al., 2015). The highest deposition of cyclohexane in rats exposed orally was in adipose tissue (Mckee et al., 2015). After oral exposure, radioactivity from labeled 2,2,4-trimethylpentane was primarily distributed to kidneys in male rats, with significantly higher levels in the kidneys of male rats compared with female rats (U.S. EPA, 2007). Other deposition sites (primarily peritoneal fat and liver) contained lower amounts of radioactivity with little difference between the sexes (U.S. EPA, 2007). Alpha-olefins (those having a double bond at the first carbon) in the C2−C10 range are primarily distributed to the brain, liver, kidneys, and peritoneal fat (OECD, 2004). In vitro air-tissue partitioning studies show that many aliphatic low carbon range compounds partition into adipose tissue (coefficients range from 39.6 to 443) and to a lesser extent into liver, brain, and kidney (coefficients ≤18.8) (Gargas et al., 1989; Perbellini et al., 1985).

Metabolism of aliphatic low carbon range compounds is largely dependent on structure (linear, branched, or cyclic; alkane or alkene). Available information indicates that alkanes are oxidatively metabolized in the liver to alcohols, ketones, carboxylic acids, dihydrodiols, and diketones, and are subsequently conjugated to glucuronide or sulfate (Mckee et al., 2015; ATSDR, 1999). OECD (2004) reported that short-chain n-alkenes are predominantly metabolized to epoxide intermediates that are subsequently converted to glycols or conjugated with glutathione and excreted as mercapturic acids. Table 5 shows the urinary metabolites identified after in vivo exposure to members of the fraction. Few in vivo data on metabolism of alkenes were identified. An in vitro study using rat and human liver microsomes exposed to 1-hexene identified two metabolites: 1-hexen-3-ol and hexen-3-one (Carreón and Herrick, 2012). Little is known about the dose dependence of aliphatic low carbon range compound metabolism; uptake and metabolism of cyclopentane was concentration-dependent, with greater amounts exhaled (and less absorbed or metabolized) at higher concentrations (20% exhaled as unmetabolized parent compound at 100 ppm, but 88% at 1,000 ppm) (Galvin and Marashi, 1999).

Table 5 Urinary Metabolites Identified for Aliphatic Low Carbon Compounds

Compound | Route | Species | Urinary Metabolites | Reference
n-Pentane; (C5 [EC5]) | Inhalation; (5% in air for 1 h) | Mouse | 2-Pentanol, 3-pentanol, 2-pentanone | U.S. EPA (2009e)
2-Methylpentane; (C6 [EC5.72]) | Inhalation; 1,500 ppm for 14 wk) | Rat | 2-Methyl-2-pentanol | Frontali et al. (1981)
3-Methylpentane; (C6 [EC5.85]) | Inhalation; (1,500 ppm for 14 wk) | Rat | 3-Methyl-3-pentanol, 3-methyl-2-pentanol | Frontali et al. (1981)
n-Hexane; (C6 [EC6]) | Inhalation; (1,000 ppm for 8 h) | Rat | 2-Hexanol, 2,5-hexanedione, 3-hexanol, 1-hexanol, 2-hexanone | U.S. EPA (2005)
Cyclohexane; (C6 [EC6.58]) | Oral; (0.3–400 mg/kg once) | Rabbit | Cyclohexanol, trans-1,2-cyclohexane-diol | Mckee et al. (2015)
Cyclohexene; (C6 [EC6.74]) | Oral; (3 mmol/kg once) | Rat | 3-Hydroxycyclohexyl mercapturic acid, 2-hydroxycyclohexylmercapturic acid | U.S. EPA (2012b)
n-Heptane; (C7 [EC7]) | Inhalation; (1,800 ppm for 6 h) | Rat | 2-Heptanol, 3-heptanol, gamma-valerolactone, 2-heptanone, 3-heptanone, 4-heptanone, 2,5-heptanedione | U.S. EPA (2016)
Methylcyclohexane; (C7 [EC7.22]) | Oral; (2–2.5 mmol/kg once) | Rabbit | trans-4-Methylcyclohexane | Mckee et al. (2015)
Methylcyclohexane; (C7 [EC7.22]) | Oral; (800 mg/kg on alternate days for 2 wk | Rat | 2-trans-Hydroxy-4-cis-methylcyclohexanol, 2-cis-hydroxy-4-trans-methylcyclohexanol, trans-3-methylcyclohexanol, 2-cis-hydroxy-4-cis-methylcyclohexanol, trans-4-methylcyclohexanol, cyclohexylmethanol | Carreón and Herrick (2012)
n-Octane; (C8 [EC8]) | Oral; (1,400 mg/kg every other day for 14 d) | Rat | 2-Octanol, 3-octanol, 5-oxohexanoic acid, 6-oxohexanoic acid | Mckee et al. (2015)
2-Methylheptane; (C8 [EC7.71]) | Oral | Rat | 2-Methyl-2,5-heptanediol, 2-methyl-5-heptanoloactone, 2-methylheptanoic acid, 2-methyl-1,2-heptanediol | Mckee et al. (2015)
2,2,4-Trimethylpentane; (C8 [EC6.98]) | Oral; (4.4 mmol/kg once) | Rat | 2,4,4-Trimethyl-2-pentanol, 2,4,4-trimethyl-1-pentanol, 2,4,4-trimethylpentanoic acid, 2,4,4-trimethyl-5-hydroxypentanoic acid, 2,2,4-trimethyl-1-pentanol, 2,2,4-trimethylpentanoic acid, 2,2,4-trimethyl-5-hydroxypentanoic acid | U.S. EPA (2007)

C = carbon; EC = equivalent carbon.

Excretion of aliphatic low carbon compounds is predominantly via exhaled air (either as parent or as CO_2_) and urine, with little excreted in feces. In rats exposed orally to cyclohexane, 60−80% (depending on dose) of the administered compound was eliminated in exhaled air (parent and metabolite compositions were not reported) and the rest was excreted via urine (Mckee et al., 2015). After oral exposure to radiolabeled 2,2,4-trimethylpentane, excretion of radioactivity occurred primarily via urine (50−67%) and exhaled air (43−49%); after inhalation exposure, urinary excretion accounted for 60−70% of the absorbed compound (U.S. EPA, 2007). Elimination of the aliphatic low carbon compounds is generally rapid; elimination half-lives of 0.13 hours for n-pentane and 14−18 hours for cyclohexane have been reported in rats and humans exposed by inhalation (Mckee et al., 2015). After inhalation exposure to n-octane, 50% of the absorbed dose was eliminated as exhaled CO_2_ within 10 hours after exposure (Mckee et al., 2015).