# 3 REVIEW OF POTENTIALLY RELEVANT DATA

## 3.1 NONCANCER EVIDENCE

Compound-specific IRIS and PPRTV documents, supplemented by the literature search findings and recent reviews of petroleum toxicity and OECD SIDS dossiers (described above), were reviewed to evaluate the available noncancer data for the aliphatic low carbon range fraction compounds. Critical effects identified with existing toxicity values include peripheral neuropathy, decreased hearing sensitivity, hepatic toxicity, decreased body weight, nasal lesions, and developmental toxicity (decreased pup weights). Appendix C summarizes the evidence provided by human and experimental animal studies of noncancer health outcomes. Table 3 presents an overview of the human and animal data available to evaluate these primary toxicological endpoints for the fraction (neurological, hepatic, body weight, gastrointestinal [GI], respiratory, and developmental). As Table 3 shows, both oral and inhalation data available to assess consistency in effects across members of the fraction are discrepant across endpoints. Body weight was the only endpoint consistently evaluated across most components and mixtures. Another important data limitation not captured in Table 3 is the lack of chronic systemic toxicity information for all but three members of the fraction. Only cyclohexene, methylcyclohexane, and commercial hexane have been tested in comprehensive systemic toxicity studies in animals exposed for at least 1 year, all by the inhalation route. Furthermore, most of the oral toxicity studies observed in this database are <13 weeks in duration, and few examined comprehensive endpoints, as most were focused on selected neurotoxicity or alpha 2u-globulin (α2u-g)-mediated renal effects in male rats. The latter effects, which if established as acting through this mechanism, are not considered to be relevant to humans (U.S. EPA, 1991), and are not discussed further in this assessment. In addition, few compounds have been tested for systemic toxicity in animals exposed orally or after chronic exposure by inhalation.

Table 3 Overview of Noncancer Human and Animal Data Availability^a,^ ^b^

CASRN | Name | C | EC | Neurological | Hepatic | Body Weight | Gastrointestinal | Respiratory | Developmental
109-66-0 | n-Pentane | 5 | 5 | H, I | I | O, I | O, I | I | O, I
287-92-3 | Cyclopentane | 5 | 5.66 | I | I | I | I | I
79-29-8 | 2,3-Dimethylbutane | 6 | 5.68 | | | O | O
107-83-5 | 2-Methylpentane | 6 | 5.72 | O, I | | O, I | O
96-14-0 | 3-Methylpentane | 6 | 5.85 | O, I | I | O, I | I | I
592-41-6 | 1-Hexene | 6 | 5.9 | O, I | O, I | O, I | O | I | O
110-54-3 | n-Hexane | 6 | 6 | H, O, I | I | O, I | O, I | I | O, I
625-27-4 | 2-Methyl-2-pentene | 6 | 6.07 | | | O | O
96-37-7 | Methylcyclopentane | 6 | 6.27 | O, I | I | O, I | O, I | I
110-82-7 | Cyclohexane | 6 | 6.59 | H, I | H, I | I | | I | I
591-76-4 | 2-Methylhexane | 7 | 6.68 | | | O | O
565-59-3 | 2,3-Dimethylpentane | 7 | 6.69 | | | O | O
110-83-8 | Cyclohexene | 6 | 6.74 | | O, I | O, I | | | O
25167-70-8 | 2,4,4-Trimethylpentene | 8 | 6.8 | O | O | O | O | O | O
540-84-1 | 2,2,4-Trimethylpentane | 8 | 6.98 | | I | O, I | O
142-82-5 | n-Heptane | 7 | 7 | H, I | H | I
108-87-2 | Methylcyclohexane | 7 | 7.22 | | H, O | I | | | O
111-66-0 | 1-Octene | 8 | 7.89 | | | O
1678-91-7 | Ethylcyclohexane | 8 | 7.89 | | O
111-65-9 | n-Octane | 8 | 8 | | | I | I | I
NA | Practical-grade hexane, 40% n-hexane | 5–6 | NA | O
NA | C6 Alkane mixture without n-hexane | 6 | NA | I | | I
NA | Commercial hexane | 6 | NA | I | I | I | I | I | I
68526-52-3 | C5–C7 Alkene mixture | 6–7 | NA | O | O | O | O | O | O

a Includes human and animal studies meeting inclusion criteria. Bolded compounds and mixtures have at least one oral or inhalation toxicity value available (see Table 2).

b Compounds are arranged by increasing EC number.

C = carbon; EC = equivalent carbon; H = human data; I = animal inhalation studies; NA = not applicable; O = animal oral studies.

Based on the review of the available data, there is evidence that oral or inhalation exposures to C6 alkanes and n-heptane can induce neurological effects; most of the other compounds in the fraction have not been explicitly tested for sensitive measures of peripheral neuropathy or hearing. Thus, consistency in effects and potency across members of the fraction cannot be adequately assessed for neurological endpoints. Information among a wider range of compounds suggests that aliphatic low carbon range fraction compounds and mixtures can induce hepatic effects in the form of increased liver weight, and that potencies are generally comparable in subchronic inhalation studies (LOAELs range from 2,763.3 to 6,294 mg/m^3^ in rats and mice), but not in subchronic oral studies (LOAELs range from 50 to 1,000 mg/kg-day in rats). However, the small number of compounds with information on liver toxicity after oral exposure, lack of chronic oral studies, and availability of chronic inhalation studies for only two fraction members limit conclusions that can be drawn for hepatic effects. Data on body-weight effects after oral and inhalation exposure to a variety of aliphatic low carbon range fraction compounds and mixtures indicate that members of the fraction can be expected to induce body-weight reductions at doses ≥400 mg/kg-day or duration-adjusted concentrations ≥1,000 mg/m^3^.

The available data are not considered adequate to evaluate consistency in effects or potencies across fraction members for GI endpoints. Respiratory effects have also not been consistently shown to be associated with oral or inhalation exposure to members of the aliphatic low carbon range fraction. Finally, too few members of the fraction have received rigorous testing for developmental effects to assess consistency in effects or potencies for these endpoints.

In summary, there is evidence to suggest consistency in body-weight changes and hepatic effects of some aliphatic low carbon range fraction members. However, there is not enough information to assess consistency across the entire fraction. Data limitations (most notably, a lack of testing for sensitive measures of peripheral neuropathy or hearing) preclude an assessment of consistency in neurological effects and potencies for fraction members. There is little evidence to indicate respiratory tract effects for compounds other than commercial hexane and n-hexane. The available data are not adequate to provide confidence in an assessment of the consistency in effects for GI tract and developmental toxicity endpoints. Finally, new studies suggest that n-hexane may elicit adverse effects on the developing female reproductive tract, but no other information is available to support this finding or to assess this endpoint for other compounds.

## 3.2 CANCER EVIDENCE

### 3.2.1 Human Studies

No relationship was found between exposure to n-hexane and the occurrence of intracranial tumors in petrochemical plant workers (U.S. EPA, 2005). No other studies of carcinogenicity in humans exposed to aliphatic low carbon range compounds have been identified.

### 3.2.2 Animal Studies—Oral

No carcinogenicity studies of animals exposed orally to compounds or mixtures in the aliphatic low carbon range fraction have been identified.

### 3.2.3 Animal Studies—Inhalation

Statistically significant increases in the incidences of liver tumors (adenomas and carcinomas) and pituitary tumors (adenomas and adenocarcinomas) were observed in female mice exposed to commercial hexane at duration-adjusted concentrations ≥366 mg/m^3^ (U.S. EPA, 2009b). There were no increases in tumor incidences among male mice or rats of either sex. The findings in female mice were the basis for characterizing the weight of evidence (WOE) as “Suggestive Evidence of Carcinogenic Potential” for commercial hexane (U.S. EPA, 2009b). A screening provisional inhalation unit risk (p-IUR) of 2 × 10^−4^ per mg/m^3^ was derived based on benchmark dose (BMD) modeling of the combined pituitary adenomas and adenocarcinomas (U.S. EPA, 2009b).

In 2-year carcinogenicity studies of rats and mice exposed to cyclohexene by inhalation, there was a statistically significant dose-related trend for increased incidence of combined hepatocellular adenomas and carcinomas at the highest dose in male rats, but not in female rats or in mice of either sex (U.S. EPA, 2012b). However, these data were not considered adequate to assess the carcinogenic potential of cyclohexene given the small increase in incidence and lack of dose-response relationship (U.S. EPA, 2012b).

In rats exposed to methylcyclohexane via inhalation (268 or 1,339 mg/m^3^) for 1 year, a statistically significant increase in testicular tumors was observed at the low exposure level (5/10 compared with 0/11 in controls) but not at the high exposure level (2/11) (U.S. EPA, 2013). No information on tumor histology was reported. Given the lack of dose-response relationship, small group sizes, and abbreviated duration of exposure, U.S. EPA (2013) did not consider these data adequate for assessment of carcinogenic potential for methylcyclohexane.

In a study examining the potential for 2,2,4-trimethylpentane to promote renal cell tumor formation, rats were exposed to 234 mg/m^3^ by inhalation for up to 61 weeks (U.S. EPA, 2007). Study groups included an initiation-only group (pre-exposed to N-ethyl-N-hydroxyethylnitrosamine in drinking water for 2 weeks), a promoter-only group (2,2,4-trimethylpentane only, 6 hours/day and 5 days/week), and an initiation-promotion group. No renal cell tumors were observed in rats exposed only to 2,2,4-trimethylpentane, and the incidence in the initiation-promotion group was not significantly different from the incidence in the initiation-only group (U.S. EPA, 2007). These data were not considered adequate for the assessment of 2,2,4-trimethylpentane carcinogenicity (U.S. EPA, 2007).

### 3.2.4 Cancer Evidence Summary

Few data with which to assess the carcinogenic potential of compounds and mixtures in the aliphatic low carbon range fraction are available. No human or animal studies examining carcinogenicity were located for any compound or mixture other than commercial hexane, n-hexane, cyclohexene, methylcyclohexane, and 2,2,4-trimethylpentane. In addition, only the inhalation data for commercial hexane were considered adequate to assess carcinogenic potential, resulting in a WOE descriptor of “Suggestive Evidence of Carcinogenic Potential.”