# 2 SUMMARY OF TOXICITY AND DOSE-RESPONSE ASSESSMENT APPROACH

Toxicity and dose-response assessment for the aliphatic low carbon range fraction depends upon selection of an indicator chemical from among the component chemicals and mixtures with existing toxicity values and entailed the four basic steps outlined here and described in more detail below. Mixtures and compounds that met structural criteria (see definition of the fraction, above) and had available toxicity values from designated sources were identified.

In Step 1 and Step 2 of the assessment, literature searches were performed for the mixtures and compounds with toxicity values and for other mixtures and compounds that are relevant to the fraction. These literature searches were conducted in February 2018 and updated most recently in August 2021, and were date-limited to identify assessments published after 2009. The searches were designed for two purposes: first, to determine whether new information suggested that toxicity values for mixtures or compounds relevant to the fraction should be updated from those identified in the U.S. EPA (2009c) PPRTV assessment for complex mixtures of aliphatic and aromatic hydrocarbons; and second, to determine whether new noncancer toxicity values or data on other mixtures or compounds meeting the structural criteria of the fraction might alter the overall understanding of the toxicity of the fraction. The third step in the assessment involved searching PubMed for new noncancer toxicity data on compounds and mixtures lacking either Integrated Risk Information System (IRIS) oral or inhalation toxicity values. These literature searches were conducted in February 2018 and were date-limited to studies published from 2007 forward, in order to capture studies that were published since the searches performed in U.S. EPA (2009c). The fourth step in the assessment involved searching of recent comprehensive reviews on the toxicity of petroleum components or classes of compounds relevant to the fraction, as well as Organisation for Economic Co-operation and Development (OECD) Screening Information Data Set (SIDS) assessments^3^ and the Petroleum High Production Volume (HPV) Testing Group website, to identify other mixtures or compounds within this carbon range with existing toxicity data that may inform hazard identification for the fraction. Toxicity data criteria included human studies of any duration by oral, inhalation, and dermal exposure, and animal studies of oral or inhalation exposure lasting at least 28 days (or any duration of gestational exposure). Mixture toxicity data were considered relevant only if the mixture composition under study was quantitatively defined to enable assessment of relevance to the fraction. Figure 2 shows a schematic depiction of the process, and further detail is provided below.

Figure 2 Selection of Compounds and Mixtures for Aliphatic Low Carbon Range Fraction Hazard Identification and Dose-Response Assessment

ATSDR = Agency for Toxic Substances and Disease Registry; C = carbon; EC = equivalent carbon; HPV = High Production Volume: IRIS = Integrated Risk Information System; OECD = Organisation for Economic Co-operation and Development; PPRTV = Provisional Peer-Reviewed Toxicity Value; RfC = reference concentration; RfD = reference dose; SIDS = Screening Information Data Set.

## 2.1 IDENTIFICATION OF RELEVANT MIXTURES AND COMPOUNDS WITH TOXICITY VALUES

The first step (see Figure 2) in assessment of the toxicity for the aliphatic low carbon range fraction was to identify constituents of the fraction that have existing toxicity values from any of the sources considered for the U.S. EPA (2009c) PPRTV assessment for complex mixtures of aliphatic and aromatic hydrocarbons (these included IRIS, PPRTVs, Agency for Toxic Substances and Disease Registry [ATSDR] Minimal Risk Levels [MRLs], Massachusetts Department of Environmental Protection [MassDEP], Total Petroleum Hydrocarbon Criteria Working Group [TPHCWG], and Health Effects Assessment Summary Tables [HEAST]). Of these sources, only IRIS, PPRTVs, and ATSDR MRLs have been updated since 2009, so only these sources were consulted for toxicity values. Based on the U.S. EPA’s previous assessments and assessment activities as well as those relevant chemicals reviewed by the MassDEP (MassDEP, 2003) or TPHCWG (Edwards et al., 1997), the U.S. EPA compiled an initial list of 26 chemicals and 1 mixture (commercial hexane) considered relevant to the fraction [see full list in Appendix A and description of approach and results in Wang et al. (2012)]. Published toxicity values were identified from the IRIS, PPRTV, and ATSDR MRL databases. At least one subchronic or chronic oral or inhalation reference value or cancer toxicity value was available for six chemicals or mixtures: n-pentane, n-hexane, methylcyclopentane, cyclohexane, commercial hexane, and n-heptane. Comprehensive toxicity assessments for 2,2,4-trimethylpentane (U.S. EPA, 2007) and methylcyclohexane (U.S. EPA, 2013) were available, but did not result in the derivation of noncancer or cancer toxicity values due to inadequate data.

In the second step (see Figure 2), all existing chemicals in the IRIS, PPRTV, and ATSDR MRL databases were searched to determine whether any other compounds or mixtures (not on the initial list) meeting the structural criteria for inclusion (C5−C8 and EC5−EC8 aliphatics) were available. Searches of the IRIS and ATSDR databases did not identify any additional compounds, but review of the PPRTV database identified two additional compounds that had toxicity values and met structural criteria for inclusion: 2,4,4-trimethylpentene and cyclohexene. To evaluate whether these compounds occur in, or co-occur with, petroleum contamination, the compounds were compared against the list of petroleum mixture constituents in the TPHCWG’s (1998) Selection of Representative TPH Fractions Based on Fate and Transport Considerations (Volume 3). In that compendium, cyclohexene was identified as a constituent of gasoline (Gustafson et al., 1997). In contrast, 2,4,4-trimethylpentene was not identified as a constituent of petroleum mixtures (Gustafson et al., 1997). However, other information indicates that 2,4,4-trimethylpentene may be added to gasoline as a fuel additive, antioxidant, or octane booster (Rankovic et al., 2015; EU, 2008; Calamur et al., 2003; Gomez and Basil, 1998). Thus, while not a natural component of petroleum, 2,4,4-trimethylpentene may co-occur with petroleum contaminants and was therefore considered relevant to the fraction. Including cyclohexene and 2,4,4-trimethylpentene brought the number of compounds or mixtures with toxicity values to eight (seven chemicals and the commercial hexane mixture). Table 2 shows the toxicity values available for these compounds.

Table 2 Summary of Available Toxicity Values for Mixtures and Constituents of Aliphatic Low Carbon Range Fraction (C5–C8, EC5–EC8)^a^

CASRN | Name | C | EC | Oral Reference Dose (mg/kg-d) | | Inhalation Reference Concentration (mg/m^3^) | | Inhalation Unit Risk (mg/m^3^)^−1^ | Oral Slope Factor (mg/kg-d)^−1^
CASRN | Name | C | EC | Subchronic | Chronic | Subchronic | Chronic | Inhalation Unit Risk (mg/m^3^)^−1^ | Oral Slope Factor (mg/kg-d)^−1^
109-66-0 | n-Pentane | 5 | 5 | − | − | 10 | 1 | − | −
110-54-3 | n-Hexane | 6 | 6 | 0.3 | − | 2 | 0.7 (IRIS) | − | −
96-37-7 | Methylcyclopentane | 6 | 6.27 | 0.4 | − | − | − | − | −
110-82-7 | Cyclohexane | 6 | 6.59 | − | − | 18 | 6 (IRIS) | − | −
Various | Commercial hexane | 6 | NA | − | − | 27 | 0.6 | 0.0002 | −
110-83-8 | Cyclohexene | 6 | 6.74 | 0.05 | 0.005 | − | 1 | − | −
142-82-5 | n-Heptane | 7 | 7 | 0.003 | 0.0003 | 4 | 0.4 | − | −
25167-70-8 | 2,4,4-Trimethylpentene | 8 | 6.8 | 0.1 | 0.01 | − | − | − | −

a Except where indicated, all toxicity values are from PPRTVs. Where more than one source reported a toxicity value, the values were selected based on the following hierarchy: IRIS > PPRTV > ATSDR > HEAST > MassDEP > TPHCWG.

Values in italics are screening provisional values obtained from an existing PPRTV assessment. Screening values are not assigned confidence statements; however, confidence in these values is presumed to be low. Screening provisional values are derived when the available data do not meet the requirements for deriving a provisional toxicity value.

ATSDR = Agency for Toxic Substances and Disease Registry; C = carbon; EC = equivalent carbon; HEAST = Health Effects Assessment Summary Tables; IRIS = Integrated Risk Information System; MassDEP = Massachusetts Department of Environmental Protection; NA = not applicable; PPRTV = Provisional Peer-Reviewed Toxicity Value; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group.

## 2.2 IDENTIFICATION OF OTHER RELEVANT TOXICITY DATA

Among the 28 compounds and 1 mixture identified (26 chemicals and 1 mixture on the initial list determined relevant, plus 2,4,4-trimethylpentene and cyclohexene identified through additional searches), there were 7 compounds and 1 mixture with toxicity values. Of the 29 fraction members, 2 (n-heptane and 2,4,4-trimethylpentene) had toxicity assessments published within the last 5 years (2016 and 2015, respectively). In Step 3 (see Figure 2), literature searches were conducted in PubMed to identify any new studies that could fill data gaps for the remaining 27 fraction members. The literature searches were conducted in February 2018, were updated in August 2021, and were date-limited to studies published from 2007 forward, in order to capture studies that were published since the searches performed for the 2009 PPRTV assessment for complex TPH mixtures. A summary of the literature search strategy is provided in Appendix A. As detailed in the appendix, studies considered relevant to hazard identification included animal studies using inhalation or oral exposure routes, in which exposures continued for at least 28 days (or any duration of gestational exposure), at least one health outcome was assessed, and an untreated or vehicle control group was included. Human studies of any duration in which exposure was known or presumed to be through oral, inhalation, or dermal routes and at least one health outcome was assessed were also considered relevant.

Results of the updated literature search are as follows. Ten human studies of occupational exposure to n-hexane were identified (Jiménez-Garza et al., 2018; Beckman et al., 2016; Hassani et al., 2014; Jia et al., 2014; Wang et al., 2014; Neghab et al., 2012; Kutlu et al., 2009; Elci et al., 2007; Prieto-Castelló et al., 2007; Puri et al., 2007). Acute human studies evaluated effects of cyclohexane following inhalation exposure (Lammers et al., 2009) or n-octane after dermal exposure (Schliemann et al., 2013) in volunteers. Animal studies of oral exposure include 8-week (Wang et al., 2017) and 24-week (Yin et al., 2014) studies of n-hexane in rats. Animal studies of inhalation exposure included a 5-week study of n-hexane in mice (Liu et al., 2012), a 30-day study of cyclohexane in mice (Campos-Ordonez et al., 2015), a 4-week study of 3-methylpentane in rats (Chung et al., 2016), 13-week studies of n-pentane (Kim et al., 2012) and n-octane (Sung et al., 2010) in rats, and two developmental studies of n-hexane in rats (Li et al., 2015; Li et al., 2014).

In Step 4 (see Figure 2), to determine whether additional relevant compounds or mixtures had been tested for repeat-dose and/or reproductive/developmental toxicity since 2007, recent reviews of petroleum toxicity (Mckee et al., 2015; Baxter, 2012; Carreón and Herrick, 2012; Saavedra et al., 2007), OECD SIDS dossiers (OECD, 2010, 2004, 2000), and the Petroleum High Production Volume (HPV) Testing Group website were searched. Mixtures considered relevant to the fraction met the following criteria:

1 at least 90% of the mixture consisted of identified compounds within the C5−C8 and/or EC5−EC8 ranges.
2 99% of the mixture consisted of aliphatic compounds (≤1% aromatic).
3 the mixture has been tested in animals in at least one repeat-dose (≥28 days) or reproductive/developmental toxicity study using inhalation or oral exposure routes and included an untreated or vehicle control group.
4 human mixture studies of any duration by oral, inhalation, and dermal exposure, and animal studies of oral or inhalation exposure lasting at least 28 days (or any duration of gestational exposure).

None of the mixtures described on the Petroleum HPV Testing Group website met these criteria. In addition to commercial hexane (already included), Mckee et al. (2015) described two other mixtures that met these criteria: a C6 mixture without n-hexane, tested in an inhalation study by Egan et al. (1980); and practical-grade hexane (≤40% n-hexane and not included in the PPRTV assessment for commercial hexane), tested in an oral study by Krasavage et al. (1980). In addition, OECD (2004) described studies of a C5−C7 alkene mixture that met these criteria. Thus, toxicity data for four mixtures were considered potentially relevant to the assessment of the aliphatic low carbon range fraction. Available information on the compositions of these mixtures is provided in Appendix B.

In addition to the two compounds with IRIS or PPRTV assessments that did not yield toxicity value derivations (2,2,4-trimethylpentane and methylcyclohexane), searches of the reviews and OECD assessments identified toxicity data for 10 additional aliphatic low carbon range compounds.^4^ Human and animal studies that met criteria outlined above were reviewed to support selection of surrogates for the aliphatic low carbon range fraction toxicity values.

## 2.3 METHODS FOR INDICATOR CHEMICAL SELECTION

Only compounds or mixtures with at least one U.S. EPA (IRIS or PPRTV) or ATSDR toxicity value (see Table 2) were considered for use as potential indicator chemicals (or indicator mixtures) for derivation of the fraction-specific toxicity values, although toxicity data for other compounds were used for hazard identification and to assess consistency in effects and potency across the components of the fraction. The method for selecting indicator chemicals was adapted from the 2009 complex TPH mixtures document (U.S. EPA, 2009c). First, mixtures consisting of fraction component chemicals were preferred over individual compounds, provided that the mixture study was adequate and the mixture exhibited in vivo toxic effects similar to those exhibited by the individual fraction components. If suitable mixture data were lacking, a representative compound exhibiting in vivo toxic effects and potency similar to those exhibited by other compounds in the fraction was chosen. In the event that components of the fraction varied widely in toxic effects or potency, the toxicity value for the most potent component (i.e., component with lowest toxicity value) was selected as an indicator chemical for the fraction. Finally, if toxicity values were available for many or most of the individual compounds in a fraction, and these compounds are typically monitored at sites of hydrocarbon contamination, then a component approach would be considered.

## 2.4 DEVELOPMENT OF EXPOSURE-RESPONSE ARRAYS

In order to assess consistency in effects and potency across the components of the fraction, experimental data from compound-specific IRIS and PPRTV documents and primary data sources (identified from literature searches) were used to create exposure-response arrays provided in Appendix C. Data were extracted only from reliable studies (e.g., studies that provided dose-response data enabling the identification of no-observed-adverse-effect levels [NOAELs] and lowest-observed-adverse-effect levels [LOAELs]). Target-organ-specific NOAELs and LOAELs were determined using the following methodology.

5 Whenever possible, NOAELs and LOAELs were identified from existing IRIS or PPRTV assessments. For chemicals in which both types of assessments were available, preference was given to IRIS (in accordance with U.S. EPA Office of Superfund Remediation and Technology Innovation [OSRTI] hierarchy of human health toxicity values for Superfund assessments). In general, these assessments explicitly identified NOAEL and LOAEL values only for the most sensitive target of toxicity, so characterization of additional adverse effect levels allowed for a comprehensive comparison of toxic effects across additional endpoints and tissues.
6 All other target-organ-specific effect levels (i.e., for targets other than the most sensitive target identified in IRIS or PPRTV assessments, and all targets evaluated in newly identified studies) were determined using professional judgment, taking into consideration factors such as statistical significance (at a p-value < 0.05), biological significance (e.g., a greater than or equal to 10% increase in liver weight), magnitude and direction of change, and study quality. In the case of chemicals with existing IRIS or PPRTV assessments, NOAELs and LOAELs could often be identified from existing study summaries.

Dose-response data were presented in exposure-response arrays by health outcome and exposure route (see Appendix C). From left to right, compounds exhibiting an effect are shown before those not exhibiting an effect, to facilitate identification of patterns. Within the group exhibiting an effect, compounds are ordered from lowest LOAEL to highest. For compounds that do not exhibit an effect, NOAELs in the arrays are ordered by EC number (low to high from left to right), with mixtures shown last. Both administered doses and exposure concentrations reported in the arrays and in the text reflect time-weighted average (TWA) exposures to facilitate comparisons across studies and compounds. Consistency across the fraction was evaluated by assessing if comparable outcomes were observed for members of the fraction, and if these effects were observed at similar dose levels.

3 The OECD Existing Chemicals Database (https://hpvchemicals.oecd.org) was reviewed for relevant categories, and dossiers for the following categories were screened: alpha-olefins, higher olefins, C5 aliphatic hydrocarbon solvents, C7−C9 aliphatic hydrocarbon solvents, and methyl- and ethylcyclohexane. A category of C6 aliphatic hydrocarbon solvents is under assessment, but dossiers and hazard characterization for this category were not available at the time of the search (October 2018).

4 The 10 additional aliphatic low carbon range compounds identified in searches of the reviews and OECD assessments are cyclopentane, 2,3-dimethylbutane, 2-methylpentane, 3-methylpentane, 1-hexene, 2-methyl-2-pentene, 2-methylhexane, 2,3-dimethylpentane, ethylcyclohexane, and 1-octene.