# 1 INTRODUCTION

This Provisional Peer-Reviewed Toxicity Value (PPRTV) assessment supports a fraction-based approach to risk assessment for mixtures of petroleum hydrocarbons (U.S. EPA, 2022, 2009c). In this approach, total petroleum hydrocarbon (TPH) fractions are defined based on expected transport in the environment and analytical methods used to quantify environmental contamination by TPH mixtures. TPH components were first classified into aliphatics and aromatics, and each of these two major fractions were further separated into low, medium, and high carbon range fractions. This PPRTV assessment describes the derivation of toxicity values for the aliphatic low carbon range fraction of TPH. The toxicity values described herein are used in the assessment of Complex Mixtures of Petroleum Hydrocarbons that is intended to replace current approaches used at TPH-contaminated sites (U.S. EPA, 2022, 2009c).

## 1.1 DEFINITION OF THE ALIPHATIC LOW CARBON RANGE FRACTION

The aliphatic low carbon range fraction includes aliphatic hydrocarbons with a carbon (C) range of C5−C8 (contains between 5 and 8 carbons, inclusive) and an equivalent carbon (EC) number^1^ index range of EC5−EC8^2^ that occur in, or co-occur with, petroleum contamination. The EC index is equivalent to the retention time of the compound on a boiling-point gas chromatography (GC) column (nonpolar capillary column), normalized to the n-alkanes (NJ DEP, 2010). EC numbers are the physical characteristic that underpin analytical separation of petroleum components. EC numbers are useful because they are more closely related to environmental mobility than carbon number. For instance, two chemicals with similar carbon numbers but different structures (e.g., aliphatic vs. aromatic) could partition differently into environmental media and, ultimately, have different environmental fates. Grouping based on EC numbers provides a consistent basis for logically placing petroleum hydrocarbon compounds into fractions because EC measures correlate with physicochemical properties such as water solubility, vapor pressure, Henry’s law constant, and soil absorption coefficient (log Koc). For example, cyclohexane, a C6 aliphatic compound, has an EC of 6.59 because its boiling point and GC retention time are approximately halfway between those of n-hexane (C6 [EC6]) and n-heptane (C7 [EC7]). Individual compounds in this fraction may include linear and branched alkanes, alkenes, and alicyclic compounds. The selection of relevant compounds and mixture is described in Section 2 and Appendix A.

## 1.2 OVERVIEW OF PHYSICOCHEMICAL PROPERTIES AND ENVIRONMENTAL FATE

The physicochemical properties for members of the aliphatic low carbon range fraction that have toxicity values are provided in Table 1. Section 2 details how the fraction members with toxicity values were identified. As Table 1 shows, the seven chemicals with toxicity values include representatives from the entire carbon range (C5−C8), and include compounds with linear, branched, cyclic, and unsaturated structures. All seven compounds are liquids at room temperature, with moderate water solubility and high vapor pressure. Some members of this fraction are expected to have high mobility in soil, indicating the potential for some members of this fraction to leach to groundwater. Measured biodegradation data for several members of the aliphatic low carbon range fraction have been reported. In Japanese Ministry of International Trade and Industry (MITI) ready biodegradation tests, n-pentane, n-hexane, and n-heptane biodegraded an estimated 96, 100, and ~100%, respectively, within 4 weeks (J-CHECK, 2010a, b, c). However, limited biodegradation of methylcyclopentane occurred under aerobic or anaerobic conditions in pure culture studies, and slow biodegradation was reported for 2,4,4-trimethylpentene, cyclohexane, and cyclohexene under aerobic conditions. Volatilization is expected to be the predominant fate process for the fraction members in the environment, based on available Henry’s law constant values. The aliphatic low carbon range hydrocarbons do not contain hydrolysable functional groups; therefore, the rate of hydrolysis is expected to be negligible for all members. In the atmosphere, photochemical degradation is expected to be slow for the saturated category members. The three unsaturated category members (cyclohexene and the two isomers of 2,4,4-trimethylpentene) are expected to have a moderate rate of photochemical degradation (NLM, 2021).

Table 1 Physicochemical Properties of Aliphatic Low Carbon Range Hydrocarbons with Toxicity Values^a^

Chemical | n-Pentane | n-Hexane | Methyl-cyclopentane | Cyclohexane | Cyclohexene | n-Heptane | 2,4,4-Trimethyl-pentene
Structure | Chemical symbol for n-Pentane | Chemical symbol for n-Hexane | Chemical symbol for Methyl-cyclopentane | Chemical symbol for Cyclohexane | Chemical symbol for Cyclohexene | Chemical symbol for n-Heptane | Chemical symbol for 2,4,4-Trimethyl-pentene; Chemical symbol for 2,4,4-Trimethyl-pentene
CASRN | 109-66-0 | 110-54-3 | 96-37-7 | 110-82-7 | 110-83-8 | 142-82-5 | 25167-70-8; (mixture of two isomers, 107-39-1 and 107-40-4)
Molecular formula | C_5_H_12_ | C_6_H_14_ | C_6_H_12_ | C_6_H_12_ | C_6_H_10_ | C_7_H_16_ | C_8_H_16_
EC number^b^ | 5.00 | 6.00 | 6.27 | 6.59 | 6.74 | 7.00 | 6.8
Molecular weight (g/mol) | 72.151 | 86.178 | 84.162 | 84.162 | 82.146 | 100.205 | 112.22
Melting point (°C) | −130 | −99.1 | −90.9 | 6.43 | −104^c^ | −90.8 | <−50^i^
Boiling point (°C) | 36.0 | 68.6 | 71.6 | 80.7 | 83.3^c^ | 98.2 | 101.4–103.6^i^
Vapor pressure (mm Hg at 25°C) | 514 | 151 | 137 | 96.9 | 89.0 | 46.0 | 43.4^i^
Henry’s law constant (atm-m^3^/mole at 25°C) | 1.25 | 1.8^d^ | 0.36^e^ | 0.150 | 0.0455 | 1.8^f^ | 0.75–0.88; (estimated)^g^
Water solubility (mol/L) | 5.93 × 10^−4^ | 1.27 × 10^−4^ | 5.01 × 10^−4^ | 7.26 × 10^−4^ | 2.58 × 10^−3^ | 3.25 × 10^−5^ | 1.8 mg/L at 20°C^i^
Log K_ow_ | 3.39 | 3.90 | 3.37 | 3.41 | 2.86 | 4.66 | 5.0^i^
Log K_oa_ | 1.96 | 2,40 | 3.11^*^ | 2.74 | 2.83 | 2.95 | 6.64–6.71; (estimated)^h^
Log K_oc_ | 455^*^ | 1.29 × 103^*^ | 467^*^ | 531^*^ | 196^*^ | 5.69 × 103^*^ | 2.75^i^

a Data were gathered from the U.S. EPA CompTox Chemicals Dashboard unless otherwise specified; https://comptox.epa.gov/dashboard

b EC number was developed by the TPHCWG and is proportional to the BP of a chemical. EC number is analogous to an n-paraffin retention time index and can be estimated using EC = 4.12 + 0.02 (BP) + 6.5 × 10^−5^ (BP)^2^ (NIST, 2020; Edwards et al., 1997; Gustafson et al., 1997).

c OECD (2002).

d U.S. EPA (2012a); HLC calculated based on measured VP/WS with user-entered inputs for WS = 9.5 mg/L and VP = 153 mm Hg.

e U.S. EPA (2012a); HLC calculated based on measured VP/WS with user-entered inputs for WS = 42 mg/L and VP = 138 mm Hg.

f U.S. EPA (2012a); HLC calculated based on measured VP/WS with user-entered inputs for WS = 3.4 mg/L and VP = 46 mm Hg.

g U.S. EPA (2012a); EPI Suite™ estimate with no user-entered inputs (Bond method); representative SMILES C(=CC(C)(C)C)(C)C and C(=C)(CC(C)(C)C)C.

h Calculated from listed values for log K_ow_ and HLC.

i OECD (2008).

* Predicted value.

BP = boiling point; C = carbon; EC = equivalent carbon; EPI Suite™ = Estimation Programs Interface Suite; HLC = Henry’s law constant; K_ow_ = octanol-water partition coefficient; K_oa_ = octanol-air partition coefficient; K_oc_ = soil adsorption coefficient; SMILES = simplified molecular input line entry system; TPHCWG = Total Petroleum Hydrocarbon Criteria Working Group; U.S. EPA = U.S. Environmental Protection Agency; VP = vapor pressure; WS = water solubility.

## 1.3 OVERVIEW OF MIXTURE ASSESSMENT METHODS

A number of different approaches have been developed and used to estimate risks and hazards posed by exposures to chemical mixtures encountered in the environment. Among the simplest of these approaches to implement is the indicator chemical approach (ATSDR, 2018). The indicator chemical approach estimates the risk or hazards of a mixture by evaluating the dose-response assessment developed for a component of the mixture to the exposure rate of the entire mixture. While it has greater uncertainty than the hazard index (HI) approach, the other approach that will be addressed in this PPRTV assessment, the indicator chemical approach, is used when there are only measures of the concentrations of this fraction (i.e., no information is available on the concentrations of individual chemicals in this fraction).

The U.S. Environmental Protection Agency (U.S. EPA) Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures (U.S. EPA, 2000, 1986) describes the following two broad categories of approaches for assessing human health risks and health hazards associated with environmental exposures to chemical mixtures: component methods and whole mixture methods. Component-based approaches, which involve analyzing the toxicity of a mixture’s individual components, have more uncertainty and are recommended when appropriate toxicity data on a complex mixture of concern, or on a sufficiently similar mixture (discussed below), are unavailable (U.S. EPA, 2000, 1986). In this PPRTV assessment, a component approach, the HI approach, is described for assessing noncancer hazards posed by exposures to the aliphatic low carbon range fraction.

Chemical mixture assessments are conducted most appropriately with quantitative dose-response information resulting from comparable exposures to the mixture of concern. If the dose-response data are insufficient to develop a health reference value for the specific mixture of concern in the environment, the second option that the U.S. EPA Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures (U.S. EPA, 2000, 1986) recommended is a “sufficient similarity” approach that uses a health reference value from a characterized surrogate mixture to estimate the hazard or risk associated with exposures to the mixture of concern. This method requires chemistry and toxicity data on both the potential surrogate mixture and the mixture of concern (e.g., a key event that is related to the apical endpoint observed in an epidemiological study or whole animal study), and a health reference value (e.g., from an in vivo study) on the surrogate mixture. If the chemistry and toxicity data indicate that the mixtures are “sufficiently similar” to one another, then the health reference value for the surrogate mixture can be used as a proxy for the mixture of concern. No data were identified that were suitable to implement a whole mixture approach.

The choice of a chemical mixtures risk assessment method is driven by the available data. Starting with the method requiring the least information and then discussing the method requiring more information, the following subsections summarize the indicator chemical approach and the HI approach. Figure 1 summarizes the two approaches and the preference for using each approach.

Figure 1 Provisional Peer-Reviewed Toxicity Approaches for the Aliphatic Low Carbon Range TPH Fraction Assessment

Two approaches are available to estimate the noncancer hazards associated with exposure to the aliphatic low range fraction. Approach selection should be driven by the available exposure data. Increased analytical characterization of fraction components allows for more refined risk estimates with less inherent uncertainty. Approach preference is inversely correlated with approach uncertainty.

HQ = hazard quotient.

### 1.3.1 Indicator Chemical Approach

When the chemical composition of a mixture or a mixture fraction is not known, or toxicity measures are only available for a few individual chemicals in a mixture, the toxicity of an individual chemical can be used as an indicator for the toxicity of a mixture or a mixture fraction (ATSDR, 2018). ATSDR (2018) describes an indicator chemical as “a chemical … selected to represent the toxicity of a mixture because it is characteristic of other components in the mixture and has adequate dose-response data.” Indicator chemical approaches are typically implemented to assess health risks in a health-protective manner; the chemical chosen as an indicator is among the best characterized toxicologically and likely among the most potent components of the mixture. The indicator chemical needs to have adequate dose-response data to indicate hazard potential or a dose-response relationship for noncancer outcomes, depending on the purpose of the assessment. The health risk value of the indicator chemical is integrated with exposure estimates for the mixture or mixture fraction to estimate health hazards associated with the fraction (i.e., calculate fraction-specific HI for a specific exposure pathway or a fraction-specific cancer risk estimate for a specific exposure pathway). This approach does not scale for potency of individual constituents; instead, it assumes that toxicity of all measured members of the fraction can be adequately estimated, given the purpose of the risk assessment, by the indicator chemical.

### 1.3.2 Hazard Index Approach

The HI approach combines estimated population exposures with toxicity information to characterize the potential for toxicological effects. The HI is not a risk estimate, in that it is not expressed as a probability, nor is it an estimate of a toxicity measure (e.g., percentage decrement in enzyme activity). Instead, the HI is an indicator of potential hazard. In the HI approach, a hazard quotient (HQ) is calculated as the ratio of human exposure (E) to a health hazard reference value (RfV) for each mixture component chemical (i) (U.S. EPA, 1986). These HQs are summed to yield the HI for the mixture. In health risk assessments, the U.S. EPA’s preferred RfVs are the reference dose (RfD) for the oral exposure route, and the reference concentration (RfC) for the inhalation exposure route.

H I = ∑_i = 1_^n^ H Q i = ∑_i = 1_^n^ (E_i_)/(R f V_i_)

The HI is based on dose addition (U.S. EPA, 2000; Svendsgaard and Hertzberg, 1994); the hazard is evaluated as the potency-weighted sum of the component exposures. The HI is dimensionless, so E and the RfV must be in the same units.

1 Based on an empirical relationship, the EC value can be estimated from a compound’s boiling point (BP; °C) using the following equation: EC = 4.12 + 0.02 (BP) + 6.5 × 10^−5^ (BP)^2^; see Gustafson et al. (1997).

2 This range reflects EC values rounded to the nearest whole number. For instance, cyclohexene (EC = 6.74) is included in this fraction because its EC value rounds to 7.