# APPENDIX D REFERENCES

API (American Petroleum Institute). (1985). Four-week oral nephrotoxicity screening study in male F344 rats. (EPA Document No. FYI-AX-1085-0460). Washington, DC: U.S. Environmental Protection Agency. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=OTS00004600
ATSDR (Agency for Toxic Substances and Disease Registry). (1999). Toxicological profile for Total Petroleum Hydrocarbons (TPH). In Govt Reports Announcements and Index (GRA and I), Issue 04, 2000. (NTIS/02921054_a). U.S. Department Of Health And Human Services, Public Health Service. https://www.atsdr.cdc.gov/toxprofiles/tp123.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Framework for assessing health impacts of multiple chemicals and other stressors (update). Washington, DC: U.S. Department of Health and Human Services. https://www.atsdr.cdc.gov/interactionprofiles/ip-ga/ipga.pdf
Baxter, CS. (2012). Alicyclic hydrocarbons. In E Bingham; B Cohrssen (Eds.), Patty’s toxicology: Volume 2 (6th ed., pp. 103–152). Hoboken, NJ: John Wiley & Sons. 10.1002/0471435139.tox050.pub2
Beckman, S; Eisen, EA; Bates, MN; Liu, S; Haegerstrom-Portnoy, G; Hammond, SK. (2016). Acquired color vision defects and hexane exposure: A study of San Francisco Bay Area automotive mechanics. Am J Epidemiol 183: 969–976. 10.1093/aje/kwv328 27188942
Calamur, N; Carrera, ME; Wilsak, RA. (2003). Butylenes. In Kirk-Othmer Encyclopedia of Chemical Technology. John Wiley & Sons, Inc. 10.1002/0471238961.0221202503011201.a01.pub2
Campos-Ordonez, T; Zarate-Lopez, D; Galvez-Contreras, AY; Moy-Lopez, N; Guzman-Muniz, J; Gonzalez-Perez, O. (2015). Cyclohexane produces behavioral deficits associated with astrogliosis and microglial reactivity in the adult hippocampus mouse brain. Cell Mol Neurobiol 35: 503–512. 10.1007/s10571-014-0146-6 25433657
Carreón, T; Herrick, RL. (2012). Aliphatic hydrocarbons. In Patty’s toxicology: Volume 2 (6th ed.). Hoboken, NJ: John Wiley & Sons. 10.1002/0471435139.tox049.pub2
Chung, YH; Shin, SH; Han, JH; Lee, YH. (2016). Subacute inhalation toxicity of 3-methylpentane. Toxicological Research 32: 245–250. 10.5487/TR.2016.32.3.245 27437092
Edwards, DA; Andriot, MD; Amoruso, MA; Tummey, AC; Bevan, CJ; Tveit, A; Hayes, LA; Youngren, SH; Nakles, DV. (1997). Total petroleum hydrocarbon criteria working group series: Volume 4: Development of fraction specific reference doses (RFDs) and reference concentrations (RFCs) for total petroleum hydrocarbons (TPH). Amherst, MA: Amherst Scientific Publishers.
Egan, G; Spencer, P; Schaumburg, H; Murray, KJ; Bischoff, M; Scala, R. (1980). n-Hexane-"free" hexane mixture fails to produce nervous system damage. Neurotoxicology 1: 515–524.
Elci, OC; Yener, G; Ucku, R. (2007). Working conditions and related neuropsychiatric problems among shoemakers in Turkey: Do child workers differ from others? Indian J Occup Environ Med 11: 9–14. 10.4103/0019-5278.32458 21957366
EU (European Union). (2008). 2,4,4-Trimethylpentene risk assessment. CAS No: 25167-70-8. Prepared by Germany on behalf of the European Union. Office of Official Publications of the European Communities. European Chemicals Agency. https://echa.europa.eu/documents/10162/10656235-2b4a-45dd-a1c6-a00312c69bd5
Frontali, N; Amantini, MC; Spagnolo, A; Guarcini, AM; Saltari, MC; Brugnone, F; Perbellini, L. (1981). Experimental neurotoxicity and urinary metabolites of the C5-C7 aliphatic hydrocarbons used as glue solvents in shoe manufacture. Clin Toxicol 18: 1357–1367. 10.3109/15563658108990344
Galvin, JB; Marashi, F. (1999). Cyclopentane. CAS#287-92-3 [Review]. J Toxicol Environ Health A 58: 57–74.10537372
Gargas, ML; Burgess, RJ; Voisard, DE; Cason, GH; Andersen, ME. (1989). Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98: 87–99. 10.1016/0041-008x(89)90137-3 2929023
Gomez, J; Basil, T, Chan, N. (1998). An overview of the use oxygenates in gasoline. California Environmental Protection Agency. California Air Resources Board. Stationary Source Division. https://www.arb.ca.gov/fuels/gasoline/pub/oxyrprt.pdf
Gustafson, JB; Griffith Tell, J; Orem, D. (1997). Total petroleum hydrocarbon criteria working group series: Volume 3: Selection of representative TPH fractions based on fate and transport considerations. Amherst, MA: Amherst Scientific Publishers. https://netforum.avectra.com/eweb/shopping/shopping.aspx?pager=1&site=aehs&webcode=shopping&prd_key=146b7eaf-c92d-4e4b-af1f-092c5735a10b
Halder, CA; Holdsworth, CE; Cockrell, BY; Piccirillo, VJ. (1985). Hydrocarbon nephropathy in male rats: Identification of the nephrotoxic components of unleaded gasoline. Toxicol Ind Health 1: 67–87. 10.1177/074823378500100305 3842552
Hassani, S; Namvar, M; Ghoreishvandi, M; Attarchi, M; Golabadi, M; Seyedmehdi, SM; Khodarahmian, M. (2014). Menstrual disturbances and hormonal changes in women workers exposed to a mixture of organic solvents in a pharmaceutical company. 28: 156.
J-CHECK (Japanese CHEmical Collaborative Knowledge database). (2010a). J-CHECK substance data: n-Heptane (CASRN 142-82-5). Available online at https://www.nite.go.jp/chem/jcheck/template.action?ano=4682&mno=2-7&cno=142-82-5&request_locale=en
J-CHECK (Japanese CHEmical Collaborative Knowledge database). (2010b). J-CHECK substance data: n-Hexane (CASRN 110-54-3). Available online at https://www.nite.go.jp/chem/jcheck/template.action?ano=3294&mno=2-0006&cno=110-54-3&request_locale=en
J-CHECK (Japanese CHEmical Collaborative Knowledge database). (2010c). J-CHECK substance data: n-Pentane (CASRN 109-66-0). Available online at https://www.nite.go.jp/chem/jcheck/template.action?ano=3193&mno=2-0005&cno=109-66-0&request_locale=en
Jia, X; Liu, Q; Zhang, Y; Dai, Y; Duan, H; Bin, P; Niu, Y; Liu, J; Zhong, L; Guo, J; Liu, X; Zheng, Y. (2014). Myelin protein zero and its antibody in serum as biomarkers of n-hexane-induced peripheral neuropathy and neurotoxicity effects. Chin Med J 127: 1536–1540. 10.3760/cma.j.issn.0366-6999.20140202 24762602
Jiménez-Garza, O; Guo, L; Byun, HM; Carrieri, M; Bartolucci, GB; Barrón-Vivanco, BS; Baccarelli, AA. (2018). Aberrant promoter methylation in genes related to hematopoietic malignancy in workers exposed to a VOC mixture. Toxicol Appl Pharmacol 339: 65–72. 10.1016/j.taap.2017.12.002 29217486
Johnson, W, Jr; Bergfeld, WF; Belsito, DV; Hill, RA; Klaassen, CD; Liebler, D; Marks, JG, Jr; Shank, RC; Slaga, TJ; Snyder, PW; Andersen, FA. (2012). Safety assessment of isoparaffins as used in cosmetics. Int J Toxicol 31: 269S–295S. 10.1177/1091581812463087 23283704
Kim, JK; Cho, HW; Han, JH; Lee, SB; Chung, YH; Rim, KT; Yang, JS. (2012). Subchronic inhalation toxicity study of n-pentane in rats. Saf Health Work 3: 224–234. 10.5491/SHAW.2012.3.3.224 23019535
Kimmerle, G; Thyssen, J. (1975). Acute, subacute and subchronic inhalation toxicity of cyclopentene. Int Arch Arbeitsmed 34: 177–184.1184198
Krasavage, WJ; O’Donoghue, JL; DiVincenzo, GD; Terhaar, CJ. (1980). The relative neurotoxicity of methyl-n-butyl ketone, n-hexane and their metabolites. Toxicol Appl Pharmacol 52: 433–441. 10.1016/0041-008X(80)90338-5 7368216
Kutlu, G; Gomceli, YB; Sonmez, T; Inan, LE. (2009). Peripheral neuropathy and visual evoked potential changes in workers exposed to n-hexane. J Clin Neurosci 16: 1296–1299. 10.1016/j.jocn.2008.12.021 19574050
Lammers, JHC, M; Emmen, HH; Muijser, H; Hoogendijk, EMG; Mckee, RH; Owen, DE; Kulig, BM. (2009). Neurobehavioral effects of cyclohexane in rat and human. Int J Toxicol 28: 488–497. 10.1177/1091581809345534 19966141
Li, H; Liu, J; Sun, Y; Wang, W; Weng, S; Xiao, S; Huang, H; Zhang, W (State University of New York). (2014). N-hexane inhalation during pregnancy alters DNA promoter methylation in the ovarian granulosa cells of rat offspring. J Appl Toxicol 34: 841–856. 10.1002/jat.2893 23740543
Li, H; Zhang, C; Ni, F; Guo, S; Wang, W; Liu, J; Lu, X; Huang, H; Zhang, W. (2015). Gestational n-hexane inhalation alters the expression of genes related to ovarian hormone production and DNA methylation states in adult female F1 rat offspring. Toxicol Lett 239: 141–151. 10.1016/j.toxlet.2015.09.018 26410608
Liu, J; Huang, HL; Pang, F; Zhang, WC. (2012). The effect of n-hexane on the gonad toxicity of female mice. Biomed Environ Sci 25: 189–196. 10.3967/0895-3988.2012.02.010 22998826
Mckee, RH; Adenuga, MD; Carrillo, JC. (2015). Characterization of the toxicological hazards of hydrocarbon solvents [Review]. Crit Rev Toxicol 45: 273–365. 10.3109/10408444.2015.1016216 25868376
Neghab, M; Soleimani, E; Khamoushian, K. (2012). Electrophysiological studies of shoemakers exposed to sub-TLV levels of n-hexane. J Occup Health 54: 376–382. 10.1539/joh.12-0029-FS 22863898
NIST (National Institute of Standards and Technology). (2020). NIST 17 GC method/retention index library [Database]. Retrieved from https://chemdata.nist.gov/dokuwiki/doku.php?id=chemdata:ridatabase
NJ DEP (New Jersey Department of Environmental Protection). (2010). Analysis of extractable petroleum hydrocarbon compounds (EPH) in aqueous and soil/sediment/sludge matrices (Revision 3 ed.). (NJDEP EPH 10/08). New Jersey Department of Environmental Protection Site Remediation Program Office of Data Quality. https://www.nj.gov/dep/srp/guidance/srra/eph_method.pdf
NLM (National Library of Medicine). (2021). Hazardous substances data bank [Database]. Bethesda, MD. Retrieved from https://www.nlm.nih.gov/databases/download/hsdb.html
OECD (Organisation for Economic Co-operation and Development). (2000). SIDS initial assessment report for 11th SIAM: alfa olefins: CAS No: 592-41-6, 111-66-0, 872-05-9, 112-41-4, 1120-36-1. https://hpvchemicals.oecd.org/ui/handler.axd?id=5d3beac7-e6b9-48ba-abb1-63506370cc5b
OECD (Organisation for Economic Co-operation and Development). (2002). SIDS initial assessment report for SIAM 15: cyclohexene (CAS No.: 110-83-8). Boston, MA: UN Environment Programme. https://hpvchemicals.oecd.org/ui/handler.axd?id=09418441-6b9f-415f-abf9-817539369a03
OECD (Organisation for Economic Co-operation and Development). (2004). SIDS initial assessment report for SIAM 19: Higher olefins category. Berlin, Germany. https://hpvchemicals.oecd.org/ui/handler.axd?id=19f3e277-fc51-4110-a9a8-1e2281d8a6b4
OECD (Organisation for Economic Co-operation and Development). (2008). SIDS initial assessment profile: 2,4,4-Trimethylpentene. https://hpvchemicals.oecd.org/UI/SIDS_Details.aspx?key=ee965409-8765-4ba6-a12c-e50f8bb9a579&idx=0
OECD (Organisation for Economic Co-operation and Development). (2010). OECD HPV chemical programme, SIDS dossier, approved at SIAM 30 (20/04/2010): Category: C7-C9 aliphatic hydrocarbon solvents.
OECD (Organisation for Economic Co-operation and Development). (2014). SIDS initial assessment profile: methyl - ethylcyclohexane category. 108-87-2 and 1678-91-7. https://hpvchemicals.oecd.org/ui/handler.axd?id=be0c4787-406c-4a4e-a27b-fd9b2f251e1d
Ono, Y; Takeuchi, Y; Hisanaga, N. (1981). A comparative study on the toxicity of n-hexane and its isomers on the peripheral nerve. Int Arch Occup Environ Health 48: 289–294. 10.1007/BF00405616 7251182
Perbellini, L; Brugnone, F; Caretta, D; Maranelli, G. (1985). Partition coefficients of some industrial aliphatic hydrocarbons (C5-C7) in blood and human tissues. Occup Environ Med 42: 162–167.
Prieto-Castelló, MJ; Hernández-Viadel, ML; Cardona, A; Marhuenda, D; Felipo, V. (2007). Activation of soluble guanylate cyclase by nitric oxide is increased in lymphocytes from both rats chronically exposed to 2,5-hexanedione and workers chronically exposed to n-hexane. Toxicology 229: 73–78. 10.1016/j.tox.2006.10.002 17125898
Puri, V; Chaudhry, N; Tatke, M. (2007). N-hexane neuropathy in screen printers. Electromyogr Clin Neurophysiol 47: 145–152.17557647
Rankovic, N; Bourhis, G; Loos, M; Dauphin, R. (2015). Knock management for dual fuel SI engines; RON evolution when mixing RON base fuels with octane boosters. Fuel 150: 41–47.
Saavedra, HM; Barbu, CM; Dameron, AA; Mullen, TJ; Crespi, VH; Weiss, PS. (2007). 1-Adamantanethiolate monolayer displacement kinetics follow a universal form. J Am Chem Soc 129: 10741–10746. 10.1021/ja071116z 17685611
Schliemann, S; Kleesz, P; Elsner, P. (2013). Protective creams fail to prevent solvent-induced cumulative skin irritation - results of a randomized double-blind study. Contact Derm 69: 363–371. 10.1111/cod.12103
Sung, JH; Choi, BG; Kim, HY; Baek, MW; Ryu, HY; Kim, YS; Choi, YK; Yu, IJ; Song, KS. (2010). Acute and subchronic inhalation toxicity of n-octane in rats. Saf Health Work 1: 192–200. 10.5491/SHAW.2010.1.2.192 22953180
Svendsgaard, DJ; Hertzberg, RC. (1994). Statistical methods for the toxicological evaluation of the additivity assumption as used in the Environmental Protection Agency chemical mixture risk assessment guidelines. In RSH Yang (Ed.), Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches (pp. 599–642). San Diego, CA: Academic Press.
Takeuchi, Y; Ono, Y; Hisanaga, N; Kitoh, J; Sugiura, Y. (1980). A comparative study on the neurotoxicity of n-pentane, n-hexane, and n-heptane in the rat. Br J Ind Med 37: 241–247. 10.1136/oem.37.3.241 7426474
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for the health risk assessment of chemical mixtures (pp. 1–38). (EPA/630/R-98/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=22567
U.S. EPA (U.S. Environmental Protection Agency). (1991). Alpha-2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. (EPA625391019F. PB92143668). Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB92143668
U.S. EPA (U.S. Environmental Protection Agency). (2000). Supplementary guidance for conducting health risk assessment of chemical mixtures (pp. 1–209). (EPA/630/R 00/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=20533
U.S. EPA (U.S. Environmental Protection Agency). (2003). Toxicological review of cyclohexane (Cas no. 110-82-7) in support of summary information on the Integrated Risk Information System (IRIS). (635R03008). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1005tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005). Toxicological review of n-hexane (CAS no. 110-54-3) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-03/012). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0486tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2007). Toxicological review of 2,2,4-trimethylpentane (Cas no. 540-84-1) in support of summary information on the Integrated Risk Information System (IRIS). (635R07003). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0614tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009a). Provisional peer-reviewed provisional subchronic toxicity values for n-hexane (CASRN 110-54-3) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/HexaneN.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009b). Provisional peer-reviewed toxicity values for commercial or practical grade hexane [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/HexaneCommercial.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009c). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/ComplexMixturesofAliphaticandAromaticHydrocarbons.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009d). Provisional peer-reviewed toxicity values for methylcyclopentane (CASRN 96-37-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Methylcyclopentane.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009e). Provisional peer-reviewed toxicity values for n-pentane (CASRN 109-66-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Pentanen.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2010). Provisional peer-reviewed toxicity values for cyclohexane (CASRN 110-82-7) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Cyclohexane.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11 [Computer Program]. Washington, DC. Retrieved from https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Provisional peer-reviewed toxicity values for cyclohexene (CASRN 110-83-8) [EPA Report]. (EPA690R12010F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Cyclohexene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2013). Provisional peer-reviewed toxicity values for methylcyclohexane (CASRN 108-87-2) [EPA Report]. (EPA690R13015F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Methylcyclohexane.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2015). Provisional peer-reviewed toxicity values for 2,4,4-trimethylpentene (CASRN 25167-70-8) [EPA Report]. (EPA690R15014F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Trimethylpentene244.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2016). Provisional peer-reviewed toxicity values for n-heptane (CASRN 142-82-5) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/HeptaneN.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2022). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH.
Wang, C; Chen, S; Wang, Z. (2014). Electrophysiological follow-up of patients with chronic peripheral neuropathy induced by occupational intoxication with n-hexane. Cell Biochem Biophys 70: 579–585. 10.1007/s12013-014-9959-7 24853719
Wang, NCY; Rice, GE; Teuschler, LK; Colman, J; Yang, RSH. (2012). An in silico approach for evaluating a fraction-based, risk assessment method for total petroleum hydrocarbon mixtures. J Toxicol 2012: 410143. 10.1155/2012/410143 22496687
Wang, S; Li, M; Wang, X; Li, X; Yin, H; Jiang, L; Han, W; Irving, G; Zeng, T; Xie, K. (2017). Diallyl trisulfide attenuated n-hexane induced neurotoxicity in rats by modulating P450 enzymes. Chem Biol Interact 265: 1–7. 10.1016/j.cbi.2017.01.013 28115069
Yang, YS; Lee, SB; Choi, SJ; Lee, BS; Heo, JD; Song, CW; Kim, HY; Kim, JC; Lee, K. (2014). Evaluation of subchronic inhalation toxicity of methylcyclopentane in rats. Food Chem Toxicol 63: 186–194. 10.1016/j.fct.2013.11.001 24239891
Yin, H; Zhang, C; Guo, Y; Shao, X; Zeng, T; Zhao, X; Xie, K. (2014). Biological exposure indices of pyrrole adducts in serum and urine for hazard assessment of n-hexane exposure. PLoS ONE 9: e86108. 10.1371/journal.pone.0086108 24465904