# APPENDIX C POTENTIALLY RELEVANT NONCANCER EVIDENCE

## DEVELOPMENT OF EXPOSURE-RESPONSE ARRAYS

As described in the main document, dose-response data were presented in exposure-response arrays by health outcome and exposure route. The following sections summarize the evidence provided by human and experimental animal studies of noncancer health outcomes. In order to assess consistency in effects and potency across the components of the fraction, experimental data from compound-specific Integrated Risk Information System (IRIS) and Provisional Peer-Reviewed Toxicity Value (PPRTV) documents and primary data sources (identified from literature searches) were used to create exposure-response arrays. Exposure-response arrays present dose-response data by health outcome and exposure route. From left to right, compounds exhibiting an effect are shown before those not exhibiting an effect, to enable identification of patterns. Within the group exhibiting an effect, compounds are ordered from lowest lowest-observed-adverse-effect levels (LOAELs) to highest. For compounds that do not exhibit an effect, no-observed-adverse-effect levels (NOAELs) in the arrays are ordered by equivalent carbon (EC) number index (low to high from left to right), with mixtures shown last. Both administered doses and exposure concentrations reported in the arrays and in text reflect time-weighted average (TWA) exposures, to facilitate comparisons across studies and compounds. Consistency across the fraction was evaluated by assessing if comparable outcomes were observed for members of the fraction, and if these effects were observed at similar dose levels. Unless otherwise specified, the term “significant,” used throughout this appendix, refers to statistical significance at a p-value < 0.05.

## NEUROLOGICAL EFFECTS

Peripheral nervous system effects are the critical effect for the subchronic and chronic reference concentrations (RfCs) and subchronic provisional reference dose (p-RfD) for n-hexane (U.S. EPA, 2009a), and a cocritical effect (with decreased body weight) for the subchronic provisional RfC (p-RfC) for commercial hexane (U.S. EPA, 2009b). A neurological endpoint (decreased hearing sensitivity) is also the critical effect for the subchronic and chronic p-RfCs for n-heptane (U.S. EPA, 2016). Neurological effects in humans have been studied for several additional fraction members, but the majority of the data pertain to peripheral neuropathy associated with n-hexane. Animal studies examining neurological effects are available for about half of the compounds or mixtures with toxicity data; however, the studies varied widely with respect to the spectrum of the neurological effects evaluated.

### Human Studies

Neurotoxicity has been observed in humans exposed to aliphatic compounds in the low carbon range fraction. n-Hexane is the most intensely-studied compound in this fraction, with studies of occupational exposure resulting in peripheral neuropathy characterized by loss of distal motor and sensory function (Wang et al., 2014; Kutlu et al., 2009; Puri et al., 2007; U.S. EPA, 2005). Clinical symptoms of neurotoxicity include weakness, motor impairment, paresthesia (burning or tingling sensation in limbs), hypoesthesia (partial loss of sensation and/or diminished sensibility), and changes in tendon reflexes and muscle tone. These symptoms were usually confined to distal portions of the limbs, and the degree of intensity depended on the extent of exposure (Wang et al., 2014; Kutlu et al., 2009; Puri et al., 2007; U.S. EPA, 2005). Electrophysiology measurements in exposed workers revealed decreased maximum conduction velocity (MCV) and reduced amplitude of the sensory nerve action potential (SNAP) (Wang et al., 2014; Kutlu et al., 2009; Puri et al., 2007; U.S. EPA, 2005). Reduced SNAP amplitude was also observed in asymptomatic workers exposed to n-hexane, and the magnitude of the effect was correlated with urinary concentrations of 2,5-hexanedione (Neghab et al., 2012). Examination of sural nerve biopsy samples showed axonal swelling, demyelination, and a selective decrease in long myelinated neurons in workers exposed to n-hexane (Puri et al., 2007; U.S. EPA, 2005).

Some human studies have suggested central nervous system (CNS) toxicity resulting from n-hexane exposure, including clinical signs of Parkinsonism (i.e., tremor, bradykinesia, and rigidity), memory loss, and impaired visual motor response to neurological assessment (U.S. EPA, 2005). Pathology and magnetic image resonance findings in these patients indicated loss of dopaminergic neurons, gliosis in the substantia nigra, and cerebral cortical atrophy. n-Hexane also affects vision in exposed workers, demonstrated by decreased visual evoked potentials, color discrimination deficits, and maculopathy, characterized by damage to blood vessels, fluid leakage into the retina, and pigment dispersion (Beckman et al., 2016; Kutlu et al., 2009; U.S. EPA, 2005).

No clinical signs of peripheral neuropathy were reported in 18 workers exposed to a solvent containing >90% n-heptane for 1−9 years (U.S. EPA, 2016). However, electrophysiology testing of 12 workers revealed a decrease in motor nerve conduction velocity (NCV) correlated with increased exposure duration and an increase in amplitude desynchronization of the evoked muscle action potential (U.S. EPA, 2016).

Neurological symptoms (i.e., fatigue, headache, dizziness) were reported in workers exposed to glue containing at least 75% cyclohexane (U.S. EPA, 2010). Electrophysiological abnormalities were also noted (i.e., shorter motor distal latency); however, workers were previously exposed to n-hexane. Other study limitations included small group sizes (n = 15−18) and poorly matched controls. No neurological symptoms were reported in a different study of workers exposed to glue containing at least 75% cyclohexane; however, the findings of this study were limited by small cohort size, discrepancies in reporting of analytical air concentrations, and absence of details related to the measured health outcomes (U.S. EPA, 2010). Print shop workers exposed to methylcyclohexane and other solvents for an average of 15 years experienced sleep apnea, mood disturbances, and decreased hand-eye coordination (U.S. EPA, 2013). Volunteers exposed to 4,000, 8,000, 14,000, or 20,000 mg/m^3^ n-heptane for up to 15 minutes reported vertigo, with severity increasing with exposure concentration (U.S. EPA, 2016). Additional effects observed at the highest concentration included hilarity, incoordination, and inability to walk straight.

Neurological effects were not observed in volunteers exposed to 15,000 mg/m^3^ n-pentane for 10 minutes (Mckee et al., 2015), or cyclohexane at 86 or 860 mg/m^3^ for 4 hours in two test sessions (U.S. EPA, 2010).

### Animal Studies

Animals exposed orally to alkane compounds containing six carbons have exhibited peripheral nervous system effects; few data on the neurotoxicity of other members of the fraction were located. Studies for which neurotoxicity effect levels could be determined are shown in an exposure-response array (see Figure C-1). Decreases in NCV occurred after oral exposure to several C6 alkanes at doses between 785 and 1,168 mg/kg-day in a comparative toxicity study by Ono et al. (1981). The relative potency of effects on NCV, based on severity of changes, was n-hexane > methylcyclopentane >2-methylpentane > 3-methylpentane. In a 24-week neurotoxicity study of n-hexane that was published after development of the PPRTV and IRIS documents for that compound (Yin et al., 2014), a LOAEL of 500 mg/kg-day was identified for gait abnormalities; this value is comparable to the LOAEL of 785 mg/kg-day identified by Ono et al. (1981) and was used as the basis for the subchronic oral p-RfD for that compound. An 8-week study focused on evaluating whether diallyl sulfide mitigates neurotoxic effects of n-hexane reported gait abnormalities and decreased grip strength in rats exposed to 3,000 mg/kg-day n-hexane (the only dose tested) (Wang et al., 2017). Krasavage et al. (1980) reported no hindlimb paralysis in a group of five male rats exposed to 4,000 mg/kg-day (5 days/week for 13 weeks) practical-grade hexane containing 40% n-hexane, but one of the five rats exhibited histologic evidence of neuropathy (giant axonal neuropathy) while no control rats exhibited this effect; the small number of animals tested and the lack of statistically significant change preclude determination of effect levels for this mixture.

Limited data in rats exposed orally to alkenes do not show evidence of neurotoxicity. Exposure to 1-hexene did not induce sciatic nerve histopathology at doses up to 1,000 mg/kg-day for 6−7 weeks (Gingell et al., 2000 as cited in OECD, 2004) and there was no change in rotarod performance at doses up to 3,365 mg/kg-day for 4 weeks (Dotti et al., 1994 as cited in OECD, 2004). Exposure of rats to 2,4,4-trimethylpentene (up to 1,000 mg/kg-day for 4 weeks) did not result in treatment-related effects on functional observational battery (FOB), sensory reactivity, grip strength, motor activity, or histopathology in the brain, spinal cord, or sciatic nerve (U.S. EPA, 2015). Similarly, oral exposure of rats to the C5−C7 alkene mixture at doses up to 1,000 mg/kg-day for 4 weeks did not alter FOB or histopathology of brain, spinal cord, or optic or peripheral nerve (Springborn Laboratories, 2003 as cited in OECD, 2004).

Neurological effects seen after inhalation exposure to aliphatic low carbon range compounds include peripheral neuropathy and related signs (abnormal gait and peripheral nerve atrophy), decreased hearing sensitivity, and mild narcosis or sedation (see Figure C-2). Studies examining CNS effects, including hearing sensitivity, are displayed in Figure C-3.

Figure C-1 Neurological Effects in Animals after Oral Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Figure C-2 Peripheral Nervous System Effects in Animals after Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Figure C-3 Hearing Sensitivity and Other Central Nervous System Effects in Animals after Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

As Figure C-2 indicates, eight compounds, commercial hexane, and the C6 alkane mixture without n-hexane have been tested for different measures of peripheral neuropathy (e.g., NCV, hindlimb spread, rotarod performance, and tibial or sciatic nerve histopathology) in studies of at least 13 weeks in duration. Of the compounds tested for any peripheral nervous system effect, only n-hexane and commercial hexane exhibited evidence of peripheral neuropathy. Of note, exposure to 2- and 3-methylpentane and methylcyclopentane by inhalation did not result in significant effects on hindlimb spread or tibial or sciatic nerve histology, despite the fact that these compounds induced effects on NCV after oral exposure (Ono et al., 1981). The study authors of the inhalation study for methylcyclopentane (Yang et al., 2014) noted that their study was likely not adequate to evaluate potential neurological effects, as specialized histopathology preparations (teased nerve fiber preparations or Epon-embedded specimens) may be necessary to detect axonal changes. Many of the other available studies suffer from similar limitations; thus, the data from these studies should not be interpreted as providing incontrovertible evidence for a lack of peripheral nerve damage.

Decreased hearing sensitivity was observed in rats following inhalation exposure to n-heptane and n-hexane (see Figure C-3), but little information is available for this endpoint. A single study of brainstem evoked potentials in rats exposed to 1,000 ppm n-hexane for 18 hours/day for 9 weeks suggested slight loss of auditory sensitivity; no effect on auditory sensitivity was seen after only 4 weeks of exposure to n-hexane (U.S. EPA, 2005). For n-heptane, decreased hearing sensitivity was the critical effect in the 4-week study used to derive the p-RfC (U.S. EPA, 2016). No other fraction members were specifically tested for auditory sensitivity. In mice and rats exposed to cyclohexane, transient decreases in the sensitivity of the animals to auditory stimuli were reported, but these effects were attributed to sedation (U.S. EPA, 2010).

Volatile hydrocarbons are well-known to induce narcotic effects after acute exposure to high concentrations (Mckee et al., 2015). In longer-term studies of cyclohexane and n-hexane at lower exposure levels, some evidence of narcosis was observed. Transient sedative effects in the absence of histopathology changes were observed in 13-week studies of rats and mice exposed to 6,886 mg/m^3^ cyclohexane (U.S. EPA, 2010); the effects were transient and generally occurred during the exposure period (U.S. EPA, 2010). Decreased activity was reported in female mice exposed to n-hexane at a concentration of 8,340 mg/m^3^; one mouse died at this exposure level (Liu et al., 2012). Narcotic effects were not reported in other studies reviewed.

In studies examining primarily other CNS endpoints (including FOB, motor activity, and histopathology of brain), no effects were seen in rats exposed by inhalation to n-pentane (U.S. EPA, 2009e), cyclopentane (Toxicity Testing Consortium, 1997 as cited in Galvin and Marashi, 1999; Kimmerle and Thyssen, 1975), 3-methylpentane (Chung et al., 2016), or commercial hexane (U.S. EPA, 2009b).

### Summary of Potentially Relevant Neurological Evidence

Available data indicate that neurological effects associated with oral or inhalation exposure to saturated members of the aliphatic low carbon range fraction include peripheral neuropathy, decreased hearing sensitivity, visual deficits, and CNS effects. The lowest LOAELs (by compound or mixture) for neurological endpoints (excluding transient effects for cyclohexane) ranged from 1,230 to 8,340 mg/m^3^ in inhalation studies in rats and mice (see Figures C-2 and C-3) and from 500 to 1,168 mg/kg-day in subchronic oral studies in rats (see Figure C-1). In contrast, the limited available data on unsaturated fraction members and mixtures (1-hexene, 2,4,4-trimethylpentene, and the C5−C7 alkene mixture) do not indicate neurological effects. There are data demonstrating a causal relationship between n-hexane exposure and peripheral neuropathy in both humans and animals. Available oral and inhalation studies of other fraction members suggest that other six carbon alkanes (including 2- and 3-methylpentane and methylcyclopentane) and commercial hexane (a mixture of primarily C6 alkanes) may also induce peripheral neuropathy. While other studies may be limited by lack of specialized histopathological evaluation for peripheral nerve damage, the remaining studies do show that compounds other than n-hexane do not induce severe peripheral neuropathy that would be observed as clinical signs (e.g., gait abnormalities). Exposure to n-hexane and n-heptane via inhalation have been shown to reduce auditory sensitivity in rats. Supporting data in humans are lacking, and no other studies evaluating this endpoint in animals exposed to other compounds in the fraction were located in the sources reviewed. Humans exposed to n-hexane have shown visual deficits, but data in animals, or in humans after exposure to other members of the fraction, were not identified. Other CNS effects have been reported to occur in humans (dizziness, headache, signs of Parkinsonism, memory loss) and animals (sedation) exposed by inhalation to several aliphatic low carbon range fraction members (n-hexane, cyclohexane, methylcyclohexane, and n-heptane).

Taken together, the available data indicate that C6 alkanes and n-heptane can induce neurological effects. However, because most of the other compounds in the fraction have not been explicitly tested for sensitive measures of peripheral neuropathy or hearing, it is not possible to evaluate the consistency in these endpoints and their potencies across members of the fraction.

## HEPATIC EFFECTS

Hepatic effects are the critical effects for the subchronic and chronic p-RfDs and chronic p-RfC for cyclohexene (U.S. EPA, 2012b), and for the subchronic and chronic p-RfD for 2,4,4-trimethylpentene (U.S. EPA, 2015). Critical hepatic effects of cyclohexene exposure included increased serum bilirubin and spongiosis hepatis, while the critical effect of 2,4,4-trimethylpentene was increased liver weight. Few human data pertaining to the hepatotoxicity of aliphatic low carbon range fraction members are available, and those data are limited to clinical chemistry measurements in workers exposed to mixtures. As shown in Table 3, data on hepatic effects in animals were located for 14 members of the fraction. In general, the hepatic endpoints evaluated in the animal studies were liver weight and histology, with a few studies measuring clinical chemistry.

### Human Studies

Few data are available to evaluate potential hepatic effects of aliphatic low carbon range fraction exposures in humans. Workers exposed to methylcyclohexane and n-heptane (in addition to toluene and xylene) exhibited statistically significant elevations of urinary bile acids, urinary 6β-hydroxycortisol, and ratio of 6β-hydroxycortisol to urinary free cortisol (considered by the study authors to be sensitive measures of hepatotoxicity) compared with the control workers with normal liver function (U.S. EPA, 2013). No differences were seen between these two groups in serum alanine aminotransferase (ALT), aspartate aminotransferase (AST), alkaline phosphatase, γ-glutamyl transferase (GGT), bilirubin, or urinary D-glucaric acid levels. No changes to clinical chemistry parameters were reported in a study of workers exposed to glue containing at least 75% cyclohexane; however, the findings of this study were limited by the small cohort size (n = 38), discrepancies in reporting of analytical air concentrations, and absence of details related to the clinical chemistry parameters that were evaluated (U.S. EPA, 2013).

### Animal Studies

As shown in Figure C-4, data on hepatic effects of oral exposure to aliphatic low carbon range compounds are limited to 4−8-week rat studies. Exposure to either >300 mg/kg-day 2,4,4-trimethylpentene (U.S. EPA, 2015) or 1,000 mg/kg-day C5−C7 alkene mixture (Springborn Laboratories, 2003 as cited in OECD, 2004) induced increases in absolute and/or relative liver weight, without concomitant histopathology changes. Rats exposed to cyclohexene for 7 weeks exhibited increased serum total bilirubin and bile acids at doses ≥50 mg/kg-day (U.S. EPA, 2012b). No changes in liver weight or histology were observed in rats exposed to 1-hexene (up to 1,000 mg/kg-day) for 6−8 weeks (Gingell et al., 2000 as cited in Carreón and Herrick, 2012; OECD, 2004).

Figure C-5 displays the exposure-response array for hepatic effects of inhalation exposures up to 26 weeks in duration. Only two fraction members were tested in longer-term (1−2-year) studies (cyclohexene and commercial hexane); these data were not arrayed as they were not considered to be comparable to the shorter-duration studies. Hepatic effects, primarily consisting of liver weight changes without effects on hepatic histopathology, were reported in rats exposed for up to 26 weeks to 3-methylpentane, commercial hexane, methylcyclopentane, cyclohexane, and n-hexane. Histologic changes in the liver were seen only with chronic exposure to cyclohexene and subchronic exposure to commercial hexane and cyclohexane. Chronic (2-year) exposure to cyclohexene resulted in an increased incidence of spongiosis hepatis at concentrations ≥720 mg/m^3^ (U.S. EPA, 2012b). Slight hemorrhage and inflammation in the livers were noted in a few male rats exposed to 5,639 mg/m^3^ commercial hexane for 13 weeks (U.S. EPA, 2009b). However, chronic (2-year) exposure to commercial hexane at concentrations up to 5,639 mg/m^3^ did not result in any histopathology changes in the livers of rats or mice (U.S. EPA, 2009b). Increased liver weights and an increase in the incidence of centrilobular hepatocellular hypertrophy were observed in rats after exposure to 24,101 mg/m^3^ cyclohexane for 13 weeks (U.S. EPA, 2010). In a companion experiment in mice, liver weights were increased without clinical chemistry or histology changes (U.S. EPA, 2010).

Exposure of rats to 2,648 mg/m^3^ 3-methylpentane for 4 weeks (Chung et al., 2016) or 3,608 mg/m^3^ methylcyclopentane for 13 weeks (Yang et al., 2014) resulted in increased relative liver weights (in the absence of body-weight changes), but no effects on histopathology. Increased relative liver weights without histopathology changes were observed in mice exposed to 6,294 mg/m^3^ n-hexane for 13 weeks, but body-weight decreases also occurred in this group (U.S. EPA, 2005). Increases in total serum cholesterol and serum albumin were observed in male, but not female, rats exposed for 13 weeks to 167 mg/m^3^ n-octane, but there were no other clinical chemistry changes or effects on liver weight or histopathology; these effects were not considered to be adverse (Sung et al., 2010). No hepatic effects were noted in rats after subchronic exposure to n-pentane (Kim et al., 2012), cyclopentane (Toxicity Testing Consortium, 1997 as cited in Galvin and Marashi, 1999; Kimmerle and Thyssen, 1975), 1-hexene (Gingell, 1999 as cited in OECD, 2004), or 2,2,4-trimethylpentane (IUCLID, 2000 as cited in Johnson et al., 2012).

Figure C-4 Hepatic Effects in Animals after Oral Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Figure C-5 Hepatic Effects in Animals after Subchronic Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

### Summary of Potentially Relevant Hepatic Evidence

Oral studies examining liver effects were limited to five compounds and one mixture (C5−C7 alkenes) in studies of 4−7 weeks in duration, and most showed increases in liver weight. Hepatic effects, primarily consisting of increased relative liver weights in the absence of body-weight changes, were also seen in inhalation studies in laboratory animals exposed to at least one compound with six, seven, and eight carbons, and with linear, branched, cyclic, and unsaturated structures. Histopathological changes in the livers of animals exposed to aliphatic low carbon range fraction members varied, consisting of hepatocellular hypertrophy in subchronic oral and inhalation studies and spongiosis hepatis in a chronic inhalation study. Lowest LOAELs (by compound or mixture) for hepatic endpoints ranged between 2,763.3 and 6,294 mg/m^3^ in subchronic inhalation studies in rats and mice (see Figure C-5) and varied from 50 to 1,000 mg/kg-day in subchronic oral studies in rats (see Figure C-4). Too few chronic studies were available to compare effects and potencies after longer exposures. In aggregate, the data suggest that many aliphatic low carbon range fraction compounds and mixtures can produce increases in rodent liver weight, occasionally in tandem with histological (hepatocellular hypertrophy) or serum chemistry (increases in bilirubin, ALT, or GGT) changes, and that potencies are generally comparable in inhalation studies, but more variable in oral studies.

## BODY-WEIGHT EFFECTS

Decreased body weight was a cocritical effect in the study used to derive the subchronic p-RfC for commercial hexane (U.S. EPA, 2009b). No human studies examining body-weight effects of aliphatic low carbon range compounds were identified in the sources reviewed.

As Table 3 shows, animal studies that examined body weight as an endpoint are available for nearly all of the compounds and mixtures with toxicity data; exceptions are ethylcyclohexane and practical-grade hexane. In this section, body-weight changes of at least 10% relative to controls in adult animals are considered LOAELs, and smaller changes are not. For studies that reported body-weight gain but did not report absolute body weights, and for studies of maternal weight gain during gestation, statistically significant changes from control are described.

### Animal Studies

Figure C-6 shows the effects of orally-administered aliphatic low carbon range compounds and mixtures on body weight; data are available for 14 compounds and one mixture, including compounds with carbon numbers across the entire range (C5−C8). Body-weight decreases were seen with several C5−C6 compounds: n-pentane, 2,3-dimethylbutane, n-hexane, 2-methyl-2-pentene, and methylcyclopentane. No effects on body weight were seen in studies of compounds of higher (EC ≥ 6.68) equivalent carbon number (U.S. EPA, 2015, 2012b; Til et al., 1986 as cited in OECD, 2004; Halder et al., 1985).

Body-weight effects in animals exposed by inhalation for subchronic (up to 16 weeks) or chronic durations (26 weeks to 2 years) are shown in Figures C-7 and C-8. In inhalation studies, reductions in body weight were reported to occur in rats and/or mice exposed for up to 16 weeks to n-hexane, 2-methylpentane, 1-hexene, and 2,2,4-trimethylpentene at concentrations >1,000 mg/m^3^; and in rats, mice, or hamsters exposed for ≥26 weeks to n-pentane, n-hexane, methylcyclohexane, and commercial hexane at concentrations ranging from 268 to 5,639 mg/m^3^.

Figure C-6 Decreases in Body Weight in Animals after Oral Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Figure C-7 Decreases in Body Weight in Animals after Subchronic (4−16 weeks) Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Figure C-8 Decreases in Body Weight in Animals after Chronic (24−104 weeks) Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Body-weight changes associated with gestational exposure are not shown in the figures. Maternal body-weight reductions were reported in pregnant rats and mice exposed during gestation to n-hexane at a concentration of 14,686 mg/m^3^ (U.S. EPA, 2005) and in pregnant rats exposed to commercial hexane (≥2,632 mg/m^3^) (U.S. EPA, 2009b) or cyclohexane (≥1,722 mg/m^3^) (U.S. EPA, 2010). No effect on maternal body weight was noted in pregnant rats exposed to n-pentane concentrations up to 7,377 mg/m^3^ on gestation days (GDs) 6−15 (U.S. EPA, 2009e).

No body-weight changes were observed in studies of adult rats, mice, or rabbits exposed by inhalation or oral administration for at least 4 weeks to cyclopentane, 3-methylpentane, n-heptane, n-octane, or the C6 alkane mixture without n-hexane.

### Summary of Potentially Relevant Body Weight Evidence

Compounds and mixtures in the aliphatic low carbon range fraction have been shown to reduce body weights of rats, mice, and hamsters after oral and inhalation exposure. Individual compounds that induced body-weight changes after inhalation exposure include compounds across the entire carbon range (C5−C8) and compounds representing linear, branched, cyclic, and unsaturated structures. Lowest LOAELs ranged between 1,414 and 5,357 mg/m^3^ in rats and between 6,294 and 8,340 mg/m^3^ in mice in subchronic inhalation studies (see Figure C-7). In chronic inhalation studies, a LOAEL of 268 mg/m^3^ was identified in hamsters; LOAELs ranged between 472 and 5,639 mg/m^3^ in rats and mice (see Figure C-8). In oral studies, body-weight decreases were seen with several C5−C6 compounds, but compounds with higher equivalent carbon numbers (EC ≥ 6.68) did not induce body-weight changes. Lowest LOAELs (by compound or mixture) for body-weight endpoints ranged between 357 and 1,500 mg/kg-day in subchronic oral studies in rats (see Figure C-6). Taken together, the inhalation and oral animal data indicate that compounds in the aliphatic low carbon range fraction can be expected to induce body-weight reductions at sufficiently high doses (generally ≥1,000 mg/kg-day for most compounds or duration-adjusted concentrations ≥1,000 mg/m^3^ after less-than-chronic exposures).

## GASTROINTESTINAL EFFECTS

The n-heptane screening subchronic and chronic p-RfDs are based on analogue read-across analysis using n-nonane as the analogue; forestomach lesions were the critical effect in the study of n-nonane (U.S. EPA, 2016). No human studies examining gastrointestinal (GI) effects of aliphatic low carbon range compounds were identified in the sources reviewed. Data on GI effects of aliphatic low carbon range compounds in animals exposed by oral and inhalation routes were limited, so exposure-response arrays are not developed for this endpoint.

### Animal Studies

The subchronic and chronic oral p-RfDs for n-heptane are based on an analogue, n-nonane (C9 [EC9]), and forestomach histopathology (hyperplasia and hyperkeratosis at doses ≥100 mg/kg-day administered by gavage as neat compound 7 days/week) (U.S. EPA, 2016). Irritation of the gastric mucosa was noted at both gross and microscopic examination of rats exposed by gavage to 1-hexene (as neat compound) at doses ≥1,010 mg/kg-day for 4 weeks (Dotti et al., 1994 as cited in OECD, 2004). No histopathology findings were observed in the stomach or large or small intestines of rats exposed to 2,4,4-trimethylpentene in maize oil at doses up to 1,000 mg/kg-day for 4 weeks (U.S. EPA, 2015) or the C5−C7 alkene mixture in corn oil at doses up to 1,000 mg/kg-day for 4−6 weeks (Springborn Laboratories, Inc., 2003 as cited in OECD, 2004). None of the remaining oral studies of compounds within the C5−C8 range evaluated GI tract histopathology, and the only related data available were gross necropsy findings in the stomach. In the unpublished version of the Halder et al. (1985) gavage study, API (1985) reported grossly observed stomach changes including ulcers, edema, and reddened areas; these effects were seen in 80−100% of the animals treated with each of the tested compounds in the C5−C8 range (affected dose groups were not reported; duration-adjusted doses tested in the study were 357 and 1,429 mg/kg-day). All of the compounds (including n-pentane, 2,3-dimethylbutane, 2-methylpentane, n-hexane, 2-methyl-2-pentene, methylcyclopentane, 2-methylhexane, 2,3-dimethylpentane, and 2,2,4-trimethylpentane) were administered neat (without solvent) in that study.

No inhalation studies of aliphatic low carbon range compounds or mixtures have identified GI effects. Studies that examined the GI tract for histopathology changes reported no effects in rats after exposure for 4−13 weeks to n-pentane (U.S. EPA, 2009e), cyclopentane (Kimmerle and Thyssen, 1975), 3-methylpentane (Chung et al., 2016), methylcyclopentane (Yang et al., 2014), or n-octane (Sung et al., 2010), or in mice exposed to n-hexane for 13 weeks (U.S. EPA, 2005). Chronic (2-year) studies of commercial hexane in rats and mice exposed by inhalation to duration-adjusted concentrations up to 5,639 mg/m^3^ also showed no treatment-related histopathology in the GI tract (U.S. EPA, 2009b).

### Summary of Potentially Relevant Gastrointestinal Evidence

Irritant responses in the GI tract were observed macroscopically in rats exposed by gavage to neat alkanes in the C5−C8 range (Halder et al., 1985), and forestomach histopathology was seen in rats exposed by gavage to neat n-nonane (the analogue for n-heptane). API (1985) and Halder et al. (1985) reported gross changes in the stomach collectively for the tested C5−C8 compounds as a group; thus, effect levels could not be determined. Histopathology changes were not seen after inhalation exposure to compounds in the fraction, and histopathology evaluations of the GI tract were lacking for most of the available oral studies. It appears from these observations that oral exposure to undiluted members of the fraction may result in direct effects on the GI tract. However, available data are not considered sufficient to evaluate the consistency in GI effects and potencies across fraction members.

## RESPIRATORY EFFECTS

Nasal and laryngeal lesions represent the critical effect for the chronic RfC for commercial hexane (U.S. EPA, 2009b). No information on respiratory effects in humans exposed to aliphatic low carbon range compounds or mixtures was identified in the sources reviewed. Animal studies examining respiratory tract endpoints are available for nine compounds and two mixtures (see Table 3); the preponderance of the animal data is from subchronic inhalation studies.

### Animal Studies

Only two of the available oral studies of compounds or mixtures relevant to the aliphatic low carbon range fraction examined respiratory tract effects in animals, and no oral studies examined nasal pathology. No histopathology changes were observed in the lungs of rats given 2,4,4-trimethylpentene at doses up to 1,000 mg/kg-day for 4 weeks (U.S. EPA, 2015) or in the lungs or tracheas of rats given the C5−C7 alkene mixture at doses up to 1,000 mg/kg-day for 4−6 weeks (Springborn Laboratories, Inc., 2003 as cited in OECD, 2004). Due to the limited data and lack of effects, an exposure-response array is not presented for respiratory effects after oral exposure.

Figure C-9 shows the exposure-response data for respiratory effects from studies of animals exposed by inhalation. Animal studies in which the nasal cavity, nasal turbinates, and/or larynx were examined after inhalation exposure include a 4-week rat study of 3-methylpentane; subchronic rat and mouse studies of n-pentane, 1-hexene, n-hexane, methylcyclopentane, and n-octane; and chronic studies of commercial hexane in rats and mice. In mice exposed to ≥629 mg/m^3^ n-hexane for 13 weeks, nasal histopathology changes included inflammation, erosion, regeneration, and metaplasia in the olfactory and/or respiratory epithelium (U.S. EPA, 2005). Nasal and laryngeal histopathology changes (hyperplasia of epithelial and goblet cells, chronic inflammation, and increased incidence of intracytoplasmic eosinophilic material in nasal turbinates; squamous metaplasia/hyperplasia of the columnar epithelium in the larynges) were observed in rats after 2 years of exposure to commercial hexane concentrations ≥564 mg/m^3^ (U.S. EPA, 2009b). No histopathology changes in the nasal cavity, nasal turbinates, and/or larynx were observed in rats exposed to n-pentane by inhalation for 13 weeks (Kim et al., 2012), 3-methylpentane for 4 weeks (Chung et al., 2016), 1-hexene for 13 weeks (Gingell, 1999 as cited in OECD, 2004), methylcyclopentane for 13 weeks (Yang et al., 2014), or n-octane for 13 weeks (Sung et al., 2010), generally at concentrations exceeding 1,000 mg/m^3^.

Few reports of lower respiratory tract effects were located in the sources reviewed. Enlargement of the air spaces in respiratory bronchioles and alveolar ducts and pulmonary fibrosis, along with papillary tumors of nonciliated bronchial epithelial cells were observed in rabbits exposed to n-hexane for 24 weeks at a concentration of 2,610 mg/m^3^ (U.S. EPA, 2005). Gestational exposure studies of commercial hexane in rats and mice reported gross observations of pulmonary color change in dams at 7,894 mg/m^3^ (U.S. EPA, 2009b). Other studies in rats or mice reported no treatment-related effects on the lung or lower respiratory tract histopathology after exposure to n-pentane, cyclopentane, 3-methylpentane, 1-hexene, methylcyclopentane, cyclohexane, or n-octane for 4−13 weeks (see Figure C-9).

### Summary of Potentially Relevant Respiratory Evidence

Respiratory effects consisting of nasal and/or laryngeal lesions were reported in animals exposed to n-hexane and commercial hexane by inhalation, and limited evidence for bronchiolar and pulmonary changes after exposure to these materials has been reported. LOAELs ranged from 629 mg/m^3^ in mice to 2,517 mg/m^3^ in rabbits (see Figure C-9). Studies of other compounds did not show effects on the upper and/or lower respiratory tract. Thus, respiratory effects have not been consistently shown to be associated with oral or inhalation exposure to members of the aliphatic low carbon range fraction.

Figure C-9 Respiratory Tract Effects in Animals after Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

## DEVELOPMENTAL EFFECTS

Developmental toxicity, manifested as reduced offspring weights, is the critical effect for the subchronic and chronic RfCs for cyclohexane (U.S. EPA, 2010, 2003). No human studies were available to address the potential for developmental toxicity of the aliphatic low carbon range total petroleum hydrocarbon (TPH) fraction. Animal studies of developmental toxicity are available for seven compounds and two mixtures; most of the data are from inhalation studies.

### Animal Studies

Developmental studies of aliphatic low carbon range compounds and mixtures in animals exposed orally include teratogenicity studies of n-pentane and n-hexane, as well as combined repeated-dose and reproductive/developmental screening studies in rats exposed to 1-hexene, cyclohexene, 2,4,4-trimethylpentene, methylcyclohexane, ethylcyclohexane, or the C5−C7 alkene mixture. In mice exposed to n-hexane on GDs 6−15, fetal birth weights were decreased at doses ≥7,920 mg/kg-day, but maternal mortalities also occurred at these doses (U.S. EPA, 2005). No developmental effects were seen in rats exposed to n-pentane at doses up to 1,000 mg/kg-day during gestation (U.S. EPA, 2009e). The screening reproductive and developmental toxicity studies showed no developmental effects at doses up to 500 mg/kg-day (cyclohexene) (U.S. EPA, 2012b) or 1,000 mg/kg-day (1-hexene, 2,4,4-trimethylpentene, methylcyclohexane, ethylcyclohexane, and the C5−C7 alkene mixture) (U.S. EPA, 2015; OECD, 2014; Gingell et al., 2000 and Springborn Laboratories, Inc., 2003 as cited in OECD, 2004); however, these studies included only limited developmental toxicity evaluations (some were limited to pup weight and viability) and did not assess teratogenicity. Due to the limited data and absence of effects, an exposure-response array is not presented for developmental effects after oral exposure.

Data on developmental toxicity in animals exposed by inhalation are available for n-pentane, n-hexane, cyclohexane, and commercial hexane. n-Pentane has been studied only in a screening-level developmental toxicity assay, while more complete developmental toxicity data in two species are available for the remaining compounds, and two-generation reproductive toxicity studies are available for cyclohexane and commercial hexane. Figure C-10 displays the exposure-response information from these studies. In the screening-level study of n-pentane, no effects on number of implantations, viable fetuses, or incidences of external malformations were observed in rats exposed to concentrations up to 7,380 mg/m^3^ on GDs 6−15 (U.S. EPA, 2009e). Decreased pup growth was observed in rats exposed to n-hexane during gestation to concentrations ≥881 mg/m^3^ (duration-adjusted) and in mice exposed to 14,686 mg/m^3^ (U.S. EPA, 2005). Increased incidences of skeletal variations were also reported in rats exposed to 14,686 mg/m^3^ n-hexane (U.S. EPA, 2005); this finding may have been influenced by decreased fetal body weights at this exposure level. In mice exposed to n-hexane during gestation, decreases in the number of live fetuses per litter were reported at concentrations ≥7,500 mg/m^3^ (Li et al., 2015; Li et al., 2014; U.S. EPA, 2005); a decrease in percent live implants and an increase in the incidence of late resorptions were also seen at 14,686 mg/m^3^ (U.S. EPA, 2005).

Figure C-10 Developmental Effects in Animals after Inhalation Exposure to Aliphatic Low Carbon Range Compounds and Mixtures

Cyclohexane induced decreases in F_1_ and F_2_ pup weights (during lactation) at a duration-adjusted concentration of 4,304 mg/m^3^ in a two-generation rat reproductive toxicity study, while no effects on fetal weights or other measures of developmental toxicity were seen in rats and rabbits exposed to cyclohexane at 6,025 mg/m^3^ during gestation [GDs 6−15 in rats or GDs 6−18 in rabbits (U.S. EPA, 2010)]. A two-generation reproductive toxicity study of commercial hexane also reported decreased F_1_ and F_2_ offspring weights (postnatal days [PNDs] 14 and 7, respectively) in rats at a duration-adjusted concentration of 5,639 mg/m^3^ (U.S. EPA, 2009b). Exposure to 7,985 mg/m^3^ commercial hexane had no effect on GD 21 fetal weights or developmental toxicity endpoints in rats when exposure was limited to GDs 6−15 (U.S. EPA, 2009b). In mice exposed to commercial hexane at 7,895 mg/m^3^ during gestation, an increase in the incidence of skeletal variations was seen in the absence of pup weight changes (U.S. EPA, 2009b).

### Summary of Potentially Relevant Developmental Evidence

Limited developmental toxicity data, which lack teratogenicity assessments, are available for n-pentane, 1-hexene, cyclohexene, 2,2,4-trimethylpentene, and the C5−C7 alkene mixture. More robust developmental toxicity data are available for n-hexane, cyclohexane, and commercial hexane. The available oral and inhalation data suggest that n-hexane, cyclohexane, and commercial hexane reduced body weights in rat offspring, while 1-hexene, cyclohexene, 2,4,4-trimethylpentene, methylcyclohexane, ethylcyclohexane, and the C5−C7 alkene mixture did not. Exposure to n-hexane and commercial hexane via inhalation increased the incidences of skeletal variations in rats and mice, respectively, when exposed during gestation, but cyclohexane and n-pentane did not; data on skeletal variations and malformations were not available for the remaining compounds. Only n-hexane exposure (by inhalation) has been shown to affect embryonic or fetal viability. In summary, too few compounds have received rigorous testing for developmental effects, so the available developmental toxicity data are not adequate to assess consistency in effects or potencies of the compounds and mixtures in the fraction.

## OTHER EFFECTS

New studies identified in the PubMed searches for n-hexane identified effects on ovarian function in female mice exposed by inhalation. Liu et al. (2012) reported reduced egg production and serum progesterone levels at duration-adjusted n-hexane exposure concentrations ≥330 mg/m^3^ and decreases in diestrus duration and number of ovarian follicles after 5 weeks of exposure (4 hours/day, 7 days/week). Alterations in the proportions of secondary and atretic ovarian follicles, estrous cycle disruptions, and changes in the secretion of progesterone and estradiol by cultured ovarian granulosa cells from exposed offspring were also reported in female offspring of mice exposed to n-hexane during gestation (Li et al., 2015; Li et al., 2014). No other studies of ovarian function in humans or animals exposed to aliphatic low carbon range compounds or mixtures were located in the sources reviewed. Takeuchi et al. (1980)