# APPENDIX B COMPOSITION OF MIXTURES RELEVANT TO THE ALIPHATIC LOW CARBON RANGE FRACTION

Information on the composition of the C5–7 alkene mixture used in the Springborn Labs study (Springborn Labs, 2003 as cited in OECD, 2004) is provided in Table B-1. Tables B-2, B-3, and B-4 list the compositions of practical-grade hexane, commercial hexane, and C6 mixture without n-hexane mixture in the Krasavage et al. (1980), U.S. EPA (2009b), and Egan et al. (1980) studies, respectively.

Table B-1 Composition of C5–C7 Alkene Mixture^a^

Category | C | Example Compounds | Percentage in Mix
C5 n-olefins | 5 | n-Pentene | 0.5%
C5 iso-olefins | 5 | 3-Methyl-1-butene/isopentene | 1.3%
C5 n-paraffins | 5 | n-Pentane | 3.3%
C5 iso-paraffins | 5 | 2-Methylbutane/isopentane | 9.3%
C6 n-olefins | 6 | n-Hexene | 10.4%
C6 iso-olefins | 6 | 4-Methyl-1-pentene/isohexene | 55.6%
C6 iso-paraffins | 6 | 2-Methylpentane/isohexane | 17.8%
C7 iso-olefins | 7 | Isoheptene | 1.0%
Total contribution from members of fraction | | | ≥99.2%

a Springborn Labs (2003) as cited in OECD (2004).

C = carbon.

Table B-2 Composition of Practical-Grade Hexane^a^

CASRN | Name | EC | C | Percentage in Mix
287-92-3 | Cyclopentane | 5.66 | 5 | 9%
79-29-8 | 2,3-Dimethylbutane | 5.68 | 6 | 24%
107-83-5 | 2-Methylpentane/isohexane | 5.72 | 6 | 1.8%
96-14-0 | 3-Methylpentane | 5.85 | 6 | 24%
110-54-3 | n-Hexane | 6 | 6 | 40%
110-82-7 | Cyclohexane | 6.59 | 6 | 2.5%
Total contribution from members of fraction | | | | 100%

a Krasavage et al. (1980).

C = carbon; EC = equivalent carbon.

Table B-3 Composition of Commercial Hexane^a^

CASRN | Name | EC | C | Percentage in Mix
107-83-5 | 2-Methylpentane/isohexane | 5.72 | 6 | 13%
96-14-0 | 3-Methylpentane | 5.85 | 6 | 16%
110-54-3 | n-Hexane | 6 | 6 | 52%
96-37-7 | Methylcyclopentane | 6.27 | 6 | 16%
110-82-7 | Cyclohexane | 6.59 | 6 | <3%
108-08-7 | 2,4-Dimethylpentane | 6.31 | 7 | <3%
Total contribution from members of fraction | | | | 100%

a U.S. EPA (2009b).

C = carbon; EC = equivalent carbon.

Table B-4 Composition of C6 Mixture without n-Hexane^a^

CASRN | Name | EC | C | Percentage in Mix
79-29-8 | 2,3-Dimethylbutane | 5.68 | 6 | 3.4%
107-83-5 | 2-Methylpentane/isohexane | 5.72 | 6 | 35.3%
96-14-0 | 3-Methylpentane | 5.85 | 6 | 30.0%
110-54-3 | n-Hexane | 6 | 6 | 0.3%
96-37-7 | Methylcyclopentane | 6.27 | 6 | 24.6%
110-82-7 | Cyclohexane | 6.59 | 6 | 6%
Total contribution from members of fraction | | | | ≥99.6%

a Egan et al. (1980).

C = carbon; EC = equivalent carbon.