# APPENDIX A LITERATURE SEARCH AND SCREENING

Literature searches were conducted in February 2018 and updated in August 2021 for studies relevant to the derivation of provisional toxicity values the aliphatic low carbon range fraction of total petroleum hydrocarbons (TPHs). The following 27 constituents (CASRNs) were included for the aliphatic low carbon range fraction: cyclohexane (110-82-7), cyclohexene (110-83-8), cyclopentane (287-92-3), 2,2-dimethylbutane (75-83-2), 2,3-dimethylbutane (79-29-8), 2,3-dimethylpentane (565-59-3), 2,4-dimethylpentane (108-08-7), 3-ethylpentane (617-78-7), commercial hexane (no CASRN), n-hexane (110-54-3), 2-methyl-2-butene (513-35-9), 2-methyl-2-pentene (625-27-4), methylcyclohexane (108-87-2), methylcyclopentane (96-37-7), 2-methylheptane (592-27-8), 3-methylheptane (589-81-1), 2-methylhexane (591-76-4), 3-methylhexane (589-34-4), 2-methylpentane (107-83-5), 3-methylpentane (96-14-0), n-octane (111-65-9), n-pentane (109-66-0), 2,2,3,3-tetramethylbutane (594-82-1), 2,2,3-trimethylbutane (464-06-2), 2,2,4-trimethylpentane (540-84-1), 2,3,3-trimethylpentane (560-21-4), and 2,3,4-trimethylpentane (565-75-3). Initial searches were date limited from 2007 to 2018 and were conducted using the U.S. Environmental Protection Agency (U.S. EPA) Health and Environmental Research Online (HERO) database of scientific literature. The PubMed database was searched using the HERO interface. The updated search was conducted similarly using the same search strings in PubMed and Web of Science from February 2018 through August 2021. There was an additional search of Agency for Toxic Substances and Disease Registry (ATSDR) and U.S. EPA documents for health risk values for fraction members.

The results of the PubMed searches (title and abstract) were screened for relevance using the Population, Exposure, Comparison, and Outcome (PECO) criteria outline in Table A-1 below. Full-text screening for relevance to hazard identification was performed using the refined PECO criteria shown in Table A-2.

Table A-1 PECO Criteria for Title and Abstract Screening of Total Petroleum Hydrocarbon Constituent Literature Search Results

PECO Element | Inclusion Criteria
Population | Humans (any population) or laboratory mammals (any life stage).
Exposure | Human: Exposure to the subject material alone or as the primary component of a mixture, known or presumed to occur by oral, inhalation, and/or dermal routes.; Animal: In vivo, exposure to the subject material alone, by oral or inhalation (including instillation) routes, for all durations of exposures (durations <28 d will be captured as supporting information), including any duration during gestation. Other routes of exposure will be captured as supporting information.
Comparison | Human: Includes any comparison/referent group (no exposure, lower exposure).; Animal: Includes concurrent negative (untreated, sham-treated, or vehicle) control.
Outcomes | Assesses any cancer or noncancer endpoint in any tissue, organ, or physiological system.

PECO = Population, Exposure, Comparison, Outcomes.

Table A-2 PECO Criteria for Full Text Screening for Relevance to Hazard Identification

PECO Element | Inclusion Criteria
Population | Humans (any population) or laboratory mammals (any life stage).
Exposure | Human: Exposure to the subject material alone or as the primary component of a mixture, known or presumed to occur by oral or inhalation routes.; Animal: In vivo, exposure to the subject material alone, by oral or inhalation routes, for durations ≥28 d or any duration during gestation.
Comparison | Human: Includes any comparison/referent group (no exposure, lower exposure).; Animal: Includes concurrent negative (untreated, sham-treated, or vehicle) control.
Outcomes | Assesses any cancer or noncancer health outcome in any tissue, organ, or physiological system.

PECO = Population, Exposure, Comparison, Outcomes.