# 2 METHODS OF FRACTION-SPECIFIC TOXICITY ASSESSMENT

## 2.1 LITERATURE SEARCHING AND DATA REVIEW

In 2009, the U.S. EPA compiled a list of individual hydrocarbons as a preliminary step in identifying potential surrogate compounds or mixtures to represent the toxicity of the fractions or compounds useful in a component-based method. The list included all individual hydrocarbons considered previously by the U.S. EPA National Center for Environmental Assessment (NCEA) Superfund Technical Support Center in the evaluation of hydrocarbons, as well as all those with toxicity data reviewed by the Massachusetts Department of Environmental Protection (MassDEP, 2003) or the TPHCWG (Edwards et al., 1997). Similarly, a list of mixtures, primarily hydrocarbon streams, was compiled from these sources. Searches were performed in the IRIS database at the time, Health Effects Assessment Summary Tables (HEAST) (U.S. EPA, 1997a), ATSDR toxicological profiles, Chemical Assessments and Related Activities (CARA) list (U.S. EPA, 1994, 1991a), and Drinking Water Standards and Health Advisories (DWSHA) list (U.S. EPA, 2006). Additionally, the California Environmental Protection Agency (CalEPA), National Toxicology Program (NTP), World Health Organization (WHO), and International Agency for Research on Cancer (IARC) were consulted for information. The U.S. EPA (2007b) High Production Volume (HPV) Challenge Program, and particularly the Petroleum HPV Testing Group publications, as well as the Organisation for Economic Co-operation and Development (OECD) HPV Program Screening Information Data Set (SIDS) documents were searched for relevant information. Additional pertinent individual compounds and mixtures encountered during this background search were added to the list for further consideration.

On the basis of the information found during these searches, compounds and mixtures that appeared to be possible candidates for use as surrogates were subjected to preliminary searching in PubMed and the Toxic Substances Control Act Test Submissions (TSCATS) database. If chosen for PPRTV assessment development on the basis of the results of the background searching or the preliminary searching, compounds and mixtures were then subjected to full literature searches of the other databases (through 2009). Details of the literature search methods for the compounds and mixtures selected for PPRTV assessment development are available in the individual documents (U.S. EPA, 2022a, b, c, d, 2009p, q, r).

For the fraction assessments that were updated in 2022 (aliphatic low carbon range fraction and aromatic medium and high carbon range fractions), only compounds or mixtures with existing U.S. EPA or ATSDR toxicity values were considered for use as potential indicator chemicals for derivation of the fraction-specific toxicity values, although toxicity data for other compounds were used for hazard identification and to assess consistency in toxic effects and potencies across the components and mixtures relevant to the fraction. Hazard identification and dose-response assessment for the updated fractions entailed the following steps: identifying mixtures and compounds that met structural criteria specific to each fraction and had available toxicity values from designated sources; searching published literature to identify other toxicity data relevant to the fraction; searching the reference list of pertinent reviews, OECD SIDS, and the Petroleum HPV Testing Group website to identify other mixtures or compounds with toxicity data that may inform hazard identification for the fraction; and evaluating all collated data to determine whether effects and/or potencies were consistent across the fraction. Additional details of the search methods for the updated fractions are available in the fraction-specific PPRTV assessments (U.S. EPA, 2022a, b, c, d, 2009p, q, r).

## 2.2 SELECTION OF APPROACH(ES) AND TOXICITY VALUE(S)

The method for selecting an approach and toxicity value(s) for the fraction was as follows. First, mixtures were preferred over individual compounds, provided that the mixture exhibited in vivo toxic effects similar to those exhibited by the individual fraction components. If suitable mixture data were lacking, but available component data indicated similar toxicity targets, a representative compound exhibiting in vivo effects and potency similar to those exhibited by other compounds in the fraction was chosen as an indicator chemical. In the event that components of the fraction varied widely in toxic effects or potency, the toxicity value for the most potent component was generally chosen as the indicator chemical for the fraction. Finally, if toxicity values were available for many or most of the individual compounds in a fraction, and these compounds are typically monitored at sites of aliphatic or aromatic hydrocarbon contamination, then a component approach would be considered.