# 1 INTRODUCTION

This Provisional Peer-Reviewed Toxicity Value (PPRTV) assessment document is the principal document outlining the methodology for assessing noncancer health hazards and cancer risks associated with exposures to petroleum hydrocarbons. The methodology uses a fraction-based approach that examines the noncancer hazards or cancer risks associated with exposure to each of six fractions defined by chemical properties, and then describes the integration of these fraction hazards and risks to evaluate hazard or risk posed by exposures to the mixture. For each petroleum hydrocarbon fraction, the methodology includes the chemical mixture hazard assessment and risk assessment methods, definition of fractions, selection of indicator chemicals or specific components for the mixture risk assessment methods, and selection of toxicity values for the indicator chemicals or the specific components. This PPRTV assessment is intended to be used in conjunction with fraction-specific PPRTV assessments (U.S. EPA, 2022a, b, c, d, 2009p, q, r) and to replace current approaches used at total petroleum hydrocarbon (TPH)-contaminated sites. The fraction-specific PPRTV assessments assess hazard and risk using applicable, but different, methods based on available data. Methods used include the indicator chemical approach, hazard index (HI) approach, relative potency factor (RPF) approach, response-addition approach, integrated addition approach, and surrogate mixture approach; these methods are summarized in Section 1.2 and described in the specific fraction documents. In this data-driven approach, the choice of method depends on the chemical analyses conducted at a site.

Contamination of the environment by petroleum hydrocarbons is widespread. The initial contaminating materials range from crude oils to a wide variety of refined fuels and lubricating oils (IPCS, 1982). These hydrocarbon products are complex mixtures containing perhaps hundreds of hydrocarbon compounds, including aliphatic compounds (straight-chain, branched-chain, and cyclic alkanes and alkenes) and aromatic compounds (benzene and alkylbenzenes, polycyclic aromatic hydrocarbons [PAHs]^1^) (Potter and Simmons, 1998). In addition, some of these products contain nonhydrocarbon additives or contaminants [see discussion in Chapter 5 of ATSDR (1999) and references therein].

Once released into the environment, the composition of a hydrocarbon product will change due to differential fate and transport of its components (i.e., some of these processes are sometimes referred to as “weathering”) (Kuppusamy et al., 2020). In general, the more soluble and/or volatile mixture components will migrate to other locations and environmental media, while other components may be degraded (e.g., by microorganisms in soils and bodies of water) (Das and Chandran, 2011), leaving the relatively nonmobile and less readily degraded compounds (i.e., a weathered product) at the original location of release (Kuppusamy et al., 2019; Truskewycz et al., 2019; Balseiro-Romero et al., 2018; Stelljes and Watkin, 1993; Dragun, 1988; Bossert and Bartha, 1986; Coleman et al., 1984). Thus, the actual aliphatic and aromatic hydrocarbon mixture at a contaminated site, to which a population could be exposed, will vary with the quantity of petroleum hydrocarbon initially released, composition of the initial hydrocarbon mixture, location, time, and environmental medium, among other factors [see discussion in Chapter 5 of ATSDR (1999)].

The assessment of human health risks posed by petroleum hydrocarbon-contaminated sites involves measurement for all chemicals that originated in crude oils or petroleum products, known as TPHs. TPH is a loosely defined aggregate that depends on the method of analysis as well as the contaminating material. By definition, TPH is the measurable amount of petroleum-based hydrocarbon in an environmental medium and represents the total mass of hydrocarbons present without identifying individual compounds (ATSDR, 1999). As TPH is not a consistently defined entity, the assessment of health effects and development of toxicity criteria for the complex mixture as a whole is problematic, although this would be the preferred approach.

Some toxicity data are available for whole, unweathered hydrocarbon products (Cooper and Mattie, 1996; Bruner et al., 1993; Kinkead et al., 1992; Kanerva et al., 1987; Gaworski et al., 1985); however, there are limitations to using the whole-product data due to composition variability caused by differences in the crude oils from which hydrocarbon products are refined, differences in the refining processes, and differences in formulations of the final products. In addition, the identity of the released material may not be known, or multiple products may have been released, potentially at different times. Toxicity data for whole hydrocarbon products that are relatively heterogeneous are not necessarily applicable to the weathered materials or petroleum hydrocarbon mixtures in the environment to which exposures occur. These environmental petroleum hydrocarbon mixtures have been transported through individual compartments in the environment and subjected to partitioning (i.e., transfer between environmental compartments) and transformation, mediated by biological, chemical, or physical agents.

The Total Petroleum Hydrocarbon Criteria Working Group (TPHCWG) estimated there to be approximately 250 individually identified hydrocarbon components of various petroleum-derived fuels and crude oil (Potter and Simmons, 1998; Weisman, 1998; Gustafson et al., 1997). Toxicity data are available for only a relatively small number of these components. Thus, any attempt to assess the health effects of TPHs from the individual hydrocarbon components is inherently uncertain because many of the known components lack appropriate toxicity data. In addition, the resources needed to analyze for all known TPH constituents are likely to be prohibitive.

In recognition of the inapplicability of whole-product toxicity data to many contamination scenarios, the impact of differential fate and transport associated with individual contaminants, the impracticality of chemically analyzing each constituent separately, and the need for risk-based assessment of petroleum hydrocarbons, an approach has been developed to assess aliphatic and aromatic petroleum hydrocarbons on the basis of fractions with similar physical and chemical properties (MassDEP, 2003; ATSDR, 1999; MassDEP, 1994).

## 1.1 DEFINITION OF THE FRACTIONS

Specific petroleum hydrocarbon fractions for risk assessment were initially defined by a consortium of governmental agencies, professional organizations, academia, and industry more than 20 years ago on the basis of physicochemical properties, environmental fate, toxicity, and analytical chemistry considerations (MassDEP, 2003; Gustafson et al., 1997; MassDEP, 1994). More recent examples of TPH risk assessment using a fraction-based approach include CCME (2021), BCMoE (2018), ARBCA (2012), and Redman et al. (2014). In brief, the components of TPHs are generally classified into aliphatics and aromatics, and each of these major fractions are then further separated into low, medium, and high carbon range fractions based on the number of carbon (C) atoms in the compounds and/or the compounds’ equivalent carbon (EC) number index.^2^ The EC index is related to the compounds’ potential transport in the environment and is equivalent to the retention time of the compounds on a boiling-point gas chromatography (GC) column (nonpolar capillary column), normalized to n-alkanes. For example, benzene, a C6 aromatic compound, has an EC of 6.5 because its boiling point and GC retention time are approximately halfway between those of n-hexane (C6 [EC6]) and n-heptane (C7 [EC7]). Further details regarding the initial fraction definitions are available in previous reports (MassDEP, 2003; Gustafson et al., 1997; MassDEP, 1994). In addition, Wang et al. (2012) used comparative molecular field analysis to assess whether chemical members of the fractions exhibit similar chemistry and found that this analysis supported the current fraction definitions.

Since the origination of the fraction method, additional toxicity information has become available for constituents of some fractions, and there have been advances in analytical characterization of petroleum hydrocarbons. U.S. EPA has reviewed and revised the analytical methods applicable to petroleum hydrocarbons; the analytical methods match the fractions developed in this PPRTV assessment.

This document is an update of the PPRTV assessments for TPHs that U.S. EPA published in 2009 (U.S. EPA, 2009a, b, c, d, e, f, g, h, i, j, k, l, m, n, o, p, q, r, s, t). The primary motivation for this update was the release of updated toxicity values from the U.S. EPA’s Integrated Risk Information System (IRIS) program and/or PPRTV assessments for several key constituents of the aliphatic low carbon range fraction and aromatic medium and high carbon range fractions. These included toxicity values for benzo[a]pyrene (BaP) (IRIS, U.S. EPA, 2017); trimethylbenzenes (TMBs) (IRIS, U.S. EPA, 2016b); n-heptane (PPRTV, U.S. EPA, 2016a); 1,1-biphenyl (IRIS, U.S. EPA, 2013b); methylcyclohexane (PPRTV, U.S. EPA, 2013a); sec-butylbenzene (PPRTV, U.S. EPA, 2012c); tert-butylbenzene (PPRTV, U.S. EPA, 2012d); fluoranthene (PPRTV, U.S. EPA, 2012b); acenaphthene (PPRTV, U.S. EPA, 2011b); n-butylbenzene (PPRTV, U.S. EPA, 2010b); cyclohexane (PPRTV, U.S. EPA, 2010a); 1-methylnaphthalene (PPRTV, U.S. EPA, 2008); and benzo[e]pyrene (BeP) (PPRTV, U.S. EPA, 2021b).

In this update, the fraction boundaries for the aliphatic low, medium, and high carbon range fractions and the aromatic low carbon range fraction remain unchanged (see Figures 1 and 2 in Section 1.2). Fraction boundaries for the aromatic medium and high carbon range fractions were revised to accomplish the following goals:

1. Align the fraction definitions with the fractions resulting from current analytical methods as a practical approach to facilitate application.
2. Avoid grouping the generally less toxic substituted benzenes (C9–C10) with PAHs, naphthalenes, and 1,1-biphenyl.

The redefined aromatic fractions are C9–C10 (EC9–EC < 11) (medium carbon range) and C10–C32 (EC11–EC35) (high carbon range). Naphthalene, which is C10 (EC11.57), is grouped with the high carbon range. Here, the U.S. EPA specifically is updating the PPRTV assessments for the aliphatic low carbon range TPH fraction (U.S. EPA, 2022a), the aromatic medium carbon range TPH fraction (U.S. EPA, 2022d), the aromatic high carbon range TPH fraction cancer assessment (U.S. EPA, 2022b), the aromatic high carbon range TPH fraction noncancer assessment (U.S. EPA, 2022c), and the TPH mixture assessment (i.e., this document).

## 1.2 OVERVIEW OF THE APPROACH

The framework for the fractionation approach to risk assessment for complex mixtures of aliphatic and aromatic petroleum hydrocarbons is derived from, and consistent with, U.S. EPA mixtures guidelines and supplemental guidance (U.S. EPA, 2000, 1986) and risk assessment guidance for the U.S. EPA Superfund program (U.S. EPA, 1989). The U.S. EPA mixtures guidance documents identify a hierarchy of preference for toxicity assessment of mixtures: data on the mixture of interest are preferred over data on sufficiently similar mixtures, and data on individual components are preferred least. As discussed above, there are limited toxicity data on mixtures of weathered petroleum contamination from varying source materials. Likewise, there are no toxicity data on the petroleum fractions that have been defined for this purpose. However, toxicity data on mixtures of fraction constituents (i.e., representing subsets of the total fraction) and on individual constituents are available. For each fraction, toxicity data for mixtures and individual components that meet the structural requirements (aliphatic or aromatic, carbon number, and/or EC number) are evaluated to select an approach to toxicity assessment for that fraction. The evaluation takes into consideration the availability of mixture toxicity data and whether the mixture is sufficiently representative of the fraction, whether available component toxicity data are likely to encompass the range of potential toxic effects for members of the fraction, and the degree to which the component toxicity data suggest that members of the fraction exert similar effects at similar doses. The analytical data needed for each approach were also considered in selecting the most appropriate approach.

Based on the results of this analysis, the toxicity of each of the six aliphatic or aromatic hydrocarbon fractions is estimated in one or more of the following ways:

- Indicator Chemical Approach
- Hazard Index Approach
- Relative Potency Factor Approach
- Response-Addition Approach
- Integrated Addition Approach
- Surrogate Mixture Approach

Additional details of these approaches are described in Section 1.3.

Figure 1 shows the fraction definitions and the toxicity assessment approaches selected for each fraction for oral noncancer assessments. Options are presented for risk assessment when exposure media are analyzed only for the fraction total concentrations (Option 1) and when exposure media are analyzed both for the fraction total concentrations and for the individual component concentrations with toxicity values (Option 2).

Figure 2 illustrates the fraction definitions and the toxicity assessment approaches selected for each fraction for noncancer assessments following inhalation exposures. Options are presented for risk assessment when exposure media are analyzed only for the fraction total concentrations (Option 1) and when exposure media are analyzed both for the fraction total concentrations and for the individual component concentrations with toxicity values (Option 2).

Figure 3 shows the fraction definition and the approaches for both oral and inhalation cancer risk assessments. For two fractions, the aliphatic high carbon range fraction and the aromatic medium carbon range fraction, the data do not support a cancer risk assessment. For the aliphatic low carbon range fraction and the aliphatic medium carbon range fraction, the data do not support a cancer assessment by the oral route of exposure and only one option is offered for each fraction to evaluate cancer risks by the inhalation route of exposure. For the aromatic low carbon range fraction, only one option is offered for oral and inhalation exposure routes. For the aromatic high carbon range fraction, the following three options are offered: (Option 1) an indicator chemical approach when exposure media are analyzed only for the fraction total concentration; (Option 2) an RPF approach when exposure media are analyzed both for the fraction total concentration and for selected individual PAHs (i.e., components with RPFs); and (Option 3) an integrated addition approach when exposure media are analyzed for the fraction total concentration, for concentrations of selected individual PAHs that have RPFs, and for concentrations of other carcinogens that have cancer risk values but are not PAHs.

Figure 1 Overview of TPH Fractions and Assessment Methods for Oral Noncancer Assessment

Figure of Overview of TPH Fractions and Assessment Methods for Oral Noncancer Assessment

Figure 2 Overview of TPH Fractions and Assessment Methods for Inhalation Noncancer Assessment

Figure of Overview of TPH Fractions and Assessment Methods for Inhalation Noncancer Assessment

Figure 3 Overview of TPH Fractions and Assessment Methods for Cancer Assessment

Overview of TPH Fractions and Assessment Methods for Cancer Assessment

The methods for assessing toxicity of the fractions are described in Section 1.3, followed by Sections 1.3.1–1.3.5, which provide details of the assessments for each fraction. Subsequent sections describe the implementation of the approach in noncancer and cancer risk assessment of petroleum contamination.

## 1.3 OVERVIEW OF MIXTURE ASSESSMENT METHODS

This section briefly describes the chemical mixtures risk assessment methods used in the TPH assessments. These methods are described in the U.S. EPA Supplementary Guidance for Conducting Health Risk Assessment of Chemical Mixtures (U.S. EPA, 2000, 1986), U.S. EPA Feasibility of Performing Cumulative Risk Assessments for Mixtures of Disinfection By-Products in Drinking Water (U.S. EPA, 2003a), and Agency for Toxic Substances and Disease Registry (ATSDR) Framework for Assessing Health Impacts of Multiple Chemicals and Other Stressors (ATSDR, 2018).

### 1.3.1 Indicator Chemical Approach

When the chemical composition of a mixture or a mixture fraction is not known, or toxicity measures are not available for individual chemicals in a mixture, the toxicity of an individual chemical can be used as an indicator for the toxicity of a mixture or a mixture fraction (ATSDR, 2018). ATSDR (2018) describes an indicator chemical as “a chemical . . . selected to represent the toxicity of a mixture because it is characteristic of other components in the mixture and has adequate dose-response data.” Indicator chemical approaches are typically implemented to assess health risks in a health-protective manner; the chemical chosen as an indicator is among the best characterized toxicologically and likely among the most potent components of the mixture. The indicator chemical needs to have adequate dose-response data to indicate hazard potential or a dose-response relationship for noncancer outcomes, depending on the purpose of the assessment. Similarly, for cancer assessments, the indicator chemical needs to have adequate dose-response data to indicate cancer potential or to develop a dose-response relationship for cancer outcomes. The health risk value of the indicator chemical is integrated with exposure estimates for the mixture or mixture fraction to estimate health hazards associated with the fraction (i.e., calculate fraction-specific HI for a specific exposure pathway or a fraction-specific cancer risk estimate for a specific exposure pathway). This approach does not scale for potency of individual constituents; instead, it assumes that the toxicity of all measured members of the fraction can be adequately estimated by the health reference value of the indicator chemical.

### 1.3.2 Hazard Index Approach

The HI approach combines estimated population exposures with toxicity information to characterize the potential for toxicological effects. The HI is not a risk estimate, in that it is not expressed as a probability, nor is it an estimate of a toxicity measure. Instead, the HI is an indicator of potential hazard. In the HI approach, a hazard quotient (HQ) is calculated as the ratio of an estimate of exposure (E) to a reference value (RfV) for each mixture component chemical (i) (U.S. EPA, 1986). These HQs are summed to yield the HI for the mixture. In health risk assessments, U.S. EPA’s preferred RfVs are the reference dose (RfD) for the oral exposure route and the reference concentration (RfC) for the inhalation exposure route.

H I = ∑_i = 1_^n^ H Q_i_ = ∑_i = 1_^n^ (E_i_)/(R f V_i_)

The HI is based on dose addition (U.S. EPA, 2000; Svendsgaard and Hertzberg, 1994); the hazard is evaluated as the potency-weighted sum of the component exposures. The HI is dimensionless, so E and the RfV have the same units.

### 1.3.3 Relative Potency Factor Approach

The RPF approach is a component-based approach that assumes components in a mixture act in a toxicologically similar manner. Such an assumption can be made when the class of chemicals comprising the mixture shares a known or suspected common mode of action (MOA). Implementing an RPF approach requires a quantitative dose-response assessment for an index chemical (IC) and pertinent scientific data that allow the toxic potency of the mixture components to be meaningfully compared to that of the IC.

Under the assumption of dose addition, the health risk associated with exposure to a mixture can be estimated as follows: initially, the chemical component doses are scaled relative to the potency of an IC, and then these scaled doses are summed and expressed as an index chemical equivalent dose (ICED) for the mixture. For any given mixture, the general equation below highlights the steps involved in estimating the ICED.

I C E D = ∑ R P F_i_ D_i_ + D_I C_

where:

IC = index chemical ICED = index chemical equivalent dose of the mixture ( e.g. , mg/kg-day or mg/m^3^ ) R P F_i_ = relative potency factor of the i th PAH detected in the mixture ( unitless ) D_i_ = dose of the i th chemical detected in the mixture ( mg/kg-day or mg/m^3^ ) D_I C_ = dose of index chemical in the mixture ( mg/kg-day or mg/m^3^ ) , given that the RPF value for the IC is 1

RPFs for individual components can be estimated using the slope factors of the ith components:

R P F_i_ = slope_i_ ÷ slope_I C_ = R / B M D_R - i_ ÷ R / B M D_R - I C_ = B M D_R - I C_ ÷ B M D_R - i_

where:

BMD = benchmark dose R = response

Next, a plausible upper bound on cancer risk can be estimated by multiplying the ICED by the cancer risk value for the IC (e.g., oral slope factor [OSF] in [mg/kg-day]^−1^, or inhalation unit risk [IUR] in [mg/m^3^]^−1^).

### 1.3.4 Response-Addition Approach

The response-addition approach assumes simple independent action for mixture chemicals that cause the same effect, assuming that each impact is an independent response. In this method, the response to the mixture is predicted by summing the risk estimates for the mixture components under the law of statistical independence. Using r_i_ for the ith component risk, the formula for predicting the n-chemical response to the mixture probability (r_mix_) for simple independent action is then:

r_mix_ (d_1_ , … , d_n_) = 1 - ∏_i = 1_^n^ (1 - r_i_ (d_i_))

and for a binary mixture is:

r_mix_ (d_1_ , d_2_) = 1 - (1 - r_1_ (d_1_)) (1 - r_2_ (d_2_)) = r_1_ (d_1_) + r_2_ (d_2_) - r_1_ (d_1_) p_2_ (d_2_)

### 1.3.5 Integrated Addition Approach

Many mixture exposures, including the aromatic high carbon range fraction, contain component chemicals that cause cancer in toxicologically dissimilar ways. This recognition of the different bioactivities associated with complex mixtures led the U.S. EPA to develop a hybrid general additivity approach that incorporated both dose addition and response addition, yielding the probabilistic risk of the adverse endpoint of concern―in this case, carcinogenic risk of the mixture. While an RPF approach may be most applicable to an assessment of cancer risk posed by PAHs comprised of the aromatic high carbon TPH fraction, other TPH members of this fraction (e.g., 1-methylnaphtalene and 1,1-biphenyl) that are not characterized as PAH in this effort may cause cancer through different MOAs. For exposures to mixtures composed of such components and when required data are available, U.S. EPA recommends the use of an integrated addition approach.

For chemicals eliciting a common endpoint, the integrated addition approach begins with separation of the mixture components into dose-additive groups (U.S. EPA, 2007a, 2003a) based on similar MOAs (i.e., “similarity groups”). Next, the assumptions of similarity within groups, and then of toxicological independence across groups, are evaluated. If there are interactions, other mixture assessment methods would be preferred. Otherwise, within each similarity group, the RPF approach is used to estimate the health risk associated with exposures to the group of chemicals. The similarity group risks are then combined across all groups using response addition to estimate the risk posed by the entire mixture (U.S. EPA, 2000). In this assessment, the MOAs of chemicals such as 1,1-biphenyl and 1-methylnaphthalene are assumed to be independent from the MOAs of the PAHs. Specific steps of the integrated addition approach include:

- Forming toxicological similarity groups based on available information on MOA (e.g., two similarity groups could cause the same effect through different MOAs); similarity groups can vary in size from a single member to many members.
- Selecting an IC for each similarity group.
- Developing RPFs for each similarity group, reflecting intragroup potency differences, and exposure estimates.
- Calculating an ICED for each similarity group, based on the RPFs and component exposure estimates.
- Calculating each similarity group mixture risk (as probability) for the common effect(s) using the IC dose-response function.
- Estimating the total mixture risk using response addition across the similarity group risk estimates using the following equation:

R_m_ = ∑ R_j_

where:

R_m_ = risk posed by the mixture R_j_ = the risk posed by the j th subgroup ( unitless )

### 1.3.6 Surrogate Mixture Approach

In some cases, chemical mixtures can be generated in a manner considered similar to a mixture (or mixture fraction) that might be encountered in the environment. Such mixtures subsequently can be tested toxicologically. When calculating an RfD, RfC, or slope factor for a whole mixture (i.e., the tested mixture), the general process is to assume the mixture can be treated the same as a single chemical and proceed with the established methodology for generating that estimate. Such RfDs, RfCs, or slope factors calculated for a whole mixture can be used as a surrogate for a mixture that was generated by a similar process and encountered in the environment (U.S. EPA, 2000).

The tested mixture needs to have adequate dose-response data to indicate hazard potential or a dose-response relationship for noncancer outcomes. Similarly, for cancer assessments, the tested mixture needs to have adequate dose-response data to indicate cancer potential or to develop a dose-response relationship for cancer outcomes. The health risk value of the tested mixture is integrated with exposure estimates for the mixture or mixture fraction to estimate health hazard associated with the fraction (i.e., calculate fraction specific HI for a specific exposure pathway or a fraction-specific cancer risk estimate for a specific exposure pathway).

1 In this document, the U.S. Environmental Protection Agency (U.S. EPA) defines PAHs as unsubstituted compounds with two to six fused aromatic rings made up only of carbon and hydrogen atoms. The definition of the PAH excludes their alkyl substituted derivatives.

2 Based on an empirical relationship, the EC index can be calculated from a compound’s boiling point (BP; °C) using the following equation: EC = 4.12 + 0.02 (BP) + 6.5 × 1^−5^ (BP)^2^; see Gustafson et al. (1997).