# APPENDIX B REFERENCES

API (American Petroleum Institute). (2021a). API | Refinery process. Available online at https://www.api.org/oil-and-natural-gas/wells-to-consumer/fuels-and-refining/refineries/how-refinery-works/refinery-processes
API (American Petroleum Institute). (2021b). Petroleum substances and categories. Available online at https://www.petroleumhpv.org/petroleum-substances-and-categories
ARBCA (Atlantic RBCA). (2012). Atlantic RBCA (risk-based corrective action) for petroleum impacted sites in Atlantic Canada version 3. http://www.atlanticrbca.com/wp-content/files_mf/1398705926ATLANTIC_RBCA_User_Guidance_v3_July_2012doc_final.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (1995). Toxicological profile for polycyclic aromatic hydrocarbons - Update [ATSDR Tox Profile]. (CIS/97/00215). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. https://www.atsdr.cdc.gov/substances/toxsubstance.asp?toxid=25
ATSDR (Agency for Toxic Substances and Disease Registry). (1999). Toxicological profile for Total Petroleum Hydrocarbons (TPH). In Govt Reports Announcements and Index (GRA and I), Issue 04, 2000. (NTIS/02921054_a). U.S. Department Of Health And Human Services, Public Health Service. https://www.atsdr.cdc.gov/toxprofiles/tp123.pdf
ATSDR (Agency for Toxic Substances and Disease Registry). (2005). Toxicological profile for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. (PB2006100004). Atlanta, GA. https://ntrl.ntis.gov/NTRL/dashboard/searchResults.xhtml?searchQuery=PB2006100004
ATSDR (Agency for Toxic Substances and Disease Registry). (2018). Framework for assessing health impacts of multiple chemicals and other stressors (update). Washington, DC: U.S. Department of Health and Human Services. https://www.atsdr.cdc.gov/interactionprofiles/ip-ga/ipga.pdf
Balseiro-Romero M; Monterroso C; Casares JJ. (2018). Environmental fate of petroleum hydrocarbons in soil: review of multiphase transport, mass transfer, and natural attenuation processes. Pedosphere 28: 833–847. 10.1016/S1002-0160(18)60046-3
BCMoE (British Columbia Ministry of Environment). (2018). Contaminated sites regulation. July. B.C. Reg. 375/96.
Benninghoff AD; Williams DE. (2013). The role of estrogen receptor β in transplacental cancer prevention by indole-3-carbinol. Cancer Prev Res 6: 339–348. 10.1158/1940-6207.CAPR-12-0311
Bingham E; Falk HL. (1969). Environmental carcinogens. The modifying effect of cocarcinogens on the threshold response. Arch Environ Health 19: 779–783. 10.1080/00039896.1969.10666930 4187174
Bossert ID; Bartha R. (1986). Structure-biodegradability relationships of polycyclic aromatic hydrocarbons in soil (pp. 490–496). Bossert, ID; Bartha, R. http://link.springer.com/10.1007/BF01607793
Bruner RH; Kinkead ER; O'Neill TP; Flemming C D; Mattie DR; Russell CA; Wall HG. (1993). The toxicologic and oncogenic potential of JP-4 jet fuel vapors in rats and mice: 12-month intermittent inhalation exposures. Fundam Appl Toxicol 20: 97–110.8432432
Castro DJ; Baird WM; Pereira CB; Giovanini J; Löhr CV; Fischer KA; Yu Z; Gonzalez FJ; Krueger SK; Williams DE. (2008a). Fetal mouse CYP1B1 and transplacental carcinogenesis from maternal exposure to dibenzo(a,l)pyrene. Cancer Prev Res 1: 128–134. 10.1158/1940-6207.CAPR-07-0004
Castro DJ; Löhr CV; Fischer KA; Pereira CB; Williams DE. (2008b). Lymphoma and lung cancer in offspring born to pregnant mice dosed with dibenzo[a,l]pyrene: the importance of in utero vs. lactational exposure. Toxicol Appl Pharmacol 233: 454–458. 10.1016/j.taap.2008.09.009 18848954
Castro DJ; Löhr CV; Fischer KA; Waters KM; Webb-Robertson BJ; Dashwood RH; Bailey GS; Williams DE. (2009). Identifying efficacious approaches to chemoprevention with chlorophyllin, purified chlorophylls and freeze-dried spinach in a mouse model of transplacental carcinogenesis. Carcinogenesis 30: 315–320. 10.1093/carcin/bgn280 19073876
Castro DJ; Yu Z; Löhr CV; Pereira CB; Giovanini JN; Fischer KA; Orner GA; Dashwood RH; Williams DE. (2008c). Chemoprevention of dibenzo[a,l]pyrene transplacental carcinogenesis in mice born to mothers administered green tea: primary role of caffeine. Carcinogenesis 29: 1581–1586. 10.1093/carcin/bgm237 18635525
CCME (Canadian Council of Ministers of the Environment). (2021). Canada-wide standard for petroleum hydrocarbons (PHC) in soil: scientific rationale supporting technical document. http://registry.mvlwb.ca/Documents/MV2010L1-0001/MV2010L1-0001%20-%20Canada%20Wide%20Standard%20for%20Petroleum%20HydroCarbons%20PHC%20in%20Soil%20-%20May12–10.pdf
Chu S; Zhang H; Maher C; McDonald JD; Zhang X; Ho SM; Yan B; Chillrud S; Perera F; Factor P; Miller RL. (2013). Prenatal and postnatal polycyclic aromatic hydrocarbon exposure, airway hyperreactivity, and beta-2 adrenergic receptor function in sensitized mouse offspring. J Toxicol 2013: 603581. 10.1155/2013/603581 24454363
Coleman E; Munch JW; Streicher RP; Ringhand P; Kopfler F. (1984). The identification and measurement of components in gasoline, kerosene, and No. 2 fuel oil that partitions into the aqueous phase after mixing. Arch Environ Contam Toxicol 13: 171–178.
Cooper JR; Mattie DR. (1996). Developmental toxicity of JP-8 jet fuel in the rat. J Appl Toxicol 16: 197–200. 10.1002/(SICI)1099-1263(199605)16:3<197::AID-JAT331>3.0.CO;2-J 8818858
Crepeaux G; Bouillaud-Kremarik P; Sikhayeva N; Rychen G; Soulimani R; Schroeder H. (2012). Late effects of a perinatal exposure to a 16 PAH mixture: Increase of anxiety-related behaviours and decrease of regional brain metabolism in adult male rats. Toxicol Lett 211: 105–113. 10.1016/j.toxlet.2012.03.005 22450773
Crepeaux G; Bouillaud-Kremarik P; Sikhayeva N; Rychen G; Soulimani R; Schroeder H. (2013). Exclusive prenatal exposure to a 16 PAH mixture does not impact anxiety-related behaviours and regional brain metabolism in adult male rats: A role for the period of exposure in the modulation of PAH neurotoxicity. Toxicol Lett 221: 40–46. 10.1016/j.toxlet.2013.05.014 23742931
Crepeaux G; Grova N; Bouillaud-Kremarik P; Sikhayeva N; Salquebre G; Rychen G; Soulimani R; Appenzeller B; Schroeder H. (2014). Short-term effects of a perinatal exposure to a 16 polycyclic aromatic hydrocarbon mixture in rats: Assessment of early motor and sensorial development and cerebral cytochrome oxidase activity in pups. Neurotoxicology 43: 90–101. 10.1016/j.neuro.2014.03.012 24709092
Das N; Chandran P. (2011). Microbial degradation of petroleum hydrocarbon contaminants: an overview. Biotechnology research international. Das, N; Chandran, P.
Dragun J. (1988). Microbial degradation of petroleum products in soil. In Soils contaminated by petroleum. New York, NY: John Wiley & Sons.
Edwards DA; Andriot MD; Amoruso MA; Tummey AC; Bevan CJ; Tveit A; Hayes LA; Youngren SH; Nakles DV. (1997). Total petroleum hydrocarbon criteria working group series: Volume 4: Development of fraction specific reference doses (RFDs) and reference concentrations (RFCs) for total petroleum hydrocarbons (TPH). Amherst, MA: Amherst Scientific Publishers.
Gaworski CL; MacEwen JD; Vernot EH; Haun CC; Leahy HF; Bruner RH; Hall L, J. R.; Mattie DR; Pitts LL. (1985). Evaluation of 90-day inhalation toxicity of petroleum and oil shale diesel fuel marine. (AAMRL-TR-85–074). Wright-Patterson Air Force Base, OH: Armstrong Aerospace Medical Research Laboratory.
Gustafson JB; Griffith Tell J; Orem D. (1997). Total petroleum hydrocarbon criteria working group series: Volume 3: Selection of representative TPH fractions based on fate and transport considerations. Amherst, MA: Amherst Scientific Publishers. https://netforum.avectra.com/eweb/shopping/shopping.aspx?pager=1&site=aehs&webcode=shopping&prd_key=146b7eaf-c92d-4e4b-af1f-092c5735a10b
Habs M; Schmähl D; Misfeld J. (1980). Local carcinogenicity of some environmentally relevant polycyclic aromatic hydrocarbons after lifelong topical application to mouse skin. Arch Geschwulstforsch 50: 266–274.7436704
Halder CA; Holdsworth CE; Cockrell BY; Piccirillo VJ. (1985). Hydrocarbon nephropathy in male rats: Identification of the nephrotoxic components of unleaded gasoline. Toxicol Ind Health 1: 67–87. 10.1177/074823378500100305 3842552
Hoffmann D; Wynder EL. (1966). Beitrag zur carcinogenen wirkung von dibenzopyrenen. Z Krebsforsch 68: 137–149. 10.1007/BF00525155 4228038
IPCS (International Programme on Chemical Safety). (1982). Selected petroleum products-environmental health criteria 20. World Health Organization. https://apps.who.int/iris/handle/10665/37065
Kanerva RL; McCracken MS; Alden CL; Stone LC. (1987). Morphogenesis of decalin-induced renal alterations in the male rat. 25: 53–61. 10.1016/0278-6915(87)90307-3
Kim A; Park M; Yoon TK; Lee WS; Ko JJ; Lee K; Bae J. (2011). Maternal exposure to benzo[b]fluoranthene disturbs reproductive performance in male offspring mice. Toxicol Lett 203: 54–61. 10.1016/j.toxlet.2011.03.003 21392559
Kinkead ER; Salins SA; Wolfe RE. (1992). Acute irritation and sensitization potential of JP-8 jet fuel. J Am Coll Toxicol B Acute Toxic Data 11: 701. 10.3109/10915819209142094
Kuppusamy S; Maddela NR; Megharaj M; Venkateswarlu K. (2019). Total petroleum hydrocarbons: environmental fate, toxicity, and remediation. Cham, Switzerland: Springer.
Kuppusamy S; Maddela NR; Megharaj M; Venkateswarlu K. (2020). Fate of total petroleum hydrocarbons in the environment. In Total Petroleum Hydrocarbons. Cham, Switzerland: Springer.
Madeen EP; Löhr CV; You H; Siddens LK; Krueger SK; Dashwood RH; Gonzalez FJ; Baird WM; Ho E; Bramer L; Waters KM; Williams DE. (2016). Dibenzo[def,p]chrysene transplacental carcinogenesis in wild-type, CYP1B1 knockout, and CYP1B1 humanized mice. Mol Carcinog 56: 163–171. 10.1002/mc.22480 26990437
MassDEP (Massachusetts Department of Environmental Protection). (1994). Interim final petroleum report: Development of health-based alternative to the total petroleum hydrocarbon (TPH) parameter. Boston, MA. https://archive.org/details/interimfinalpetr00mass
MassDEP (Massachusetts Department of Environmental Protection). (2003). Updated petroleum hydrocarbon fraction toxicity values for the VPH/EPH/APH methodology. Boston, MA. https://www.mass.gov/files/documents/2016/08/ok/tphtox03.pdf
NIST (National Institute of Standards and Technology). (2020). NIST special publication 922: Polycyclic aromatic hydrocarbon structure index. U.S. Department of Commerce Technology Administration. https://www.nist.gov/system/files/documents/2020/08/03/sp922_2020.pdf
NTP (National Toxicology Program). (2009). Toxicology and carcinogenesis studies of cumene (CAS NO. 98–82-8) in F344/N rats and B6C3F1 mice (inhalation studies) [NTP] (pp. 1–200). (NTP TR 542; NIH Publication No. 09–5885). Research Triangle Park, NC. http://ntp.niehs.nih.gov/results/pubs/longterm/reports/longterm/tr500580/listedreports/tr542/index.html
Ono Y; Takeuchi Y; Hisanaga N. (1981). A comparative study on the toxicity of n-hexane and its isomers on the peripheral nerve. Int Arch Occup Environ Health 48: 289–294. 10.1007/BF00405616 7251182
Potter TL; Simmons KE. (1998). Total petroleum hydrocarbon criteria working group series: Volume 2: Composition of petroleum mixtures. Amherst, MA: Amherst Scientific Publishers.
Redman AD; Parkerton TF; Comber MH; Paumen ML; Eadsforth CV; Dmytrasz B; Djemel N. (2014). PETRORISK: A risk assessment framework for petroleum substances. Integrated environmental assessment and management. 10: 437–448.24687890
Rice G; Teuschler L; Simmons JE; Hertzberg RC. (2005). Mixtures, toxicology and risk assessment. In Wexler P (Ed.), Encyclopedia of toxicology (2nd ed., pp. 120–123). New York: Elsevier Press.
Shorey LE; Castro DJ; Baird WM; Siddens LK; Löhr CV; Matzke MM; Waters KM; Corley RA; Williams DE. (2012). Transplacental carcinogenesis with dibenzo[def,p]chrysene (DBC): Timing of maternal exposures determines target tissue response in offspring. Cancer Lett 317: 49–55. 10.1016/j.canlet.2011.11.010 22085489
Shorey LE; Madeen EP; Atwell LL; Ho E; Löhr CV; Pereira CB; Dashwood RH; Williams DE. (2013). Differential modulation of dibenzo[def,p]chrysene transplacental carcinogenesis: Maternal diets rich in indole-3-carbinol versus sulforaphane. Toxicol Appl Pharmacol 270: 60–69. 10.1016/j.taap.2013.02.016 23566957
Stelljes ME; Watkin GE. (1993). Comparison of environmental impacts posed by different hydrocarbon mixtures - a need for site-specific composition analyses (pp. 549–569). Boca Raton: Lewis Publishers Inc.
Svendsgaard DJ; Hertzberg RC. (1994). Statistical methods for the toxicological evaluation of the additivity assumption as used in the Environmental Protection Agency chemical mixture risk assessment guidelines. In RSH Yang (Ed.), Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches (pp. 599–642). San Diego, CA: Academic Press.
TERA (Toxicology Excellence for Risk Assessment). (2004). n-Alkane category: Decane, undecane, dodecane (CAS Nos. 124–18-5, 1120–21-4, 112–40-3): Voluntary children's chemical evaluation program (VCCEP) tier 1 pilot submission. (Docket Number OPPTS – 00274D). Cincinnati, OH. https://www.tera.org/Peer/VCCEP/n-alkanes/VCCEP%20n-Alkanes%20Submission%20Jun%2017%202004%20-%20revised.pdf
Truskewycz A; Gundry TD; Khudur LS; Kolobaric A; Taha M; Aburto-Medina A; Shahsavari E. (2019). Petroleum hydrocarbon contamination in terrestrial ecosystems—fate and microbial responses [Review]. Molecules 24: 3400. 10.3390/molecules24183400 31546774
U.S. EPA (U.S. Environmental Protection Agency). (1986). Guidelines for the health risk assessment of chemical mixtures (pp. 1–38). (EPA/630/R-98/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=22567
U.S. EPA (U.S. Environmental Protection Agency). (1989). Risk assessment guidance for superfund, volume I: Human health evaluation manual (Part A). Interim final. (EPA/540/1–89/002). Washington, DC. https://www.epa.gov/sites/production/files/2015-09/documents/rags_a.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990a). Integrated Risk Information System (IRIS) chemical assessment summary for acenaphthene (CASRN 83–32-9). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0442_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990b). Integrated Risk Information System (IRIS) chemical assessment summary for anthracene (CASRN 120–12-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0434_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990c). Integrated Risk Information System (IRIS) chemical assessment summary for fluoranthene (CASRN 206–44-0). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0444_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990d). Integrated Risk Information System (IRIS) chemical assessment summary for fluorene (CASRN 86–73-7). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0435_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1990e). Integrated Risk Information System (IRIS) chemical assessment summary for pyrene (CASRN 129–00-0). Washington, DC: National Center for Environmental Assessment, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0445_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1991a). Chemical assessments and related activities (CARA) [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment.
U.S. EPA (U.S. Environmental Protection Agency). (1991b). Integrated Risk Information System (IRIS): Chemical assessment summary for ethylbenzene (CASRN 100–41-4) [EPA Report]. Washington DC. http://www.epa.gov/iris/subst/0051.htm
U.S. EPA (U.S. Environmental Protection Agency). (1993). Provisional guidance for quantitative risk assessment of polycyclic aromatic hydrocarbons. (EPA/600/R-93/089). Cincinnati, OH: Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=49732
U.S. EPA (U.S. Environmental Protection Agency). (1994). Chemical assessments and related activities (CARA) [EPA Report]. (EPA/600/R-94/904; OHEA-I-127). Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=60001G8L.txt
U.S. EPA (U.S. Environmental Protection Agency). (1997a). Health effects assessment summary tables: FY 1997 update [EPA Report]. (EPA540R97036). Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000O0GZ.txt
U.S. EPA (U.S. Environmental Protection Agency). (1997b). Toxicological review of cumene (CAS no. 98–82-8) in support of summary information on the Integrated Risk Information System [EPA Report]. (EPA63SR98001). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0306tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (1998). Toxicological review of naphthalene (CAS no. 91–20-3) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. Washington, DC: Integrated Risk Information System. https://iris.epa.gov/static/pdfs/0436tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2000). Supplementary guidance for conducting health risk assessment of chemical mixtures (pp. 1–209). (EPA/630/R-00/002). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=20533
U.S. EPA (U.S. Environmental Protection Agency). (2003a). The feasibility of performing cumulative risk assessments for mixtures of disinfection by-products in drinking water. (EPA/600/R-03/051). Cincinnati, OH: Environmental Protection Agency, National Center for Environmental Assessment. https://cfpub.epa.gov/si/si_public_record_report.cfm?dirEntryId=56834
U.S. EPA (U.S. Environmental Protection Agency). (2003b). Integrated Risk Information System (IRIS): Chemical assessment summary for benzene (CASRN 71–43-2). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0276_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2003c). Integrated Risk Information System (IRIS): Chemical assessment summary for xylenes (CASRN 1330–20-7). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0270_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2003d). Toxicological review of 2-methylnaphthalene (CASRN 91–57-6) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA635R03010). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1006tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2003e). Toxicological review of cyclohexane (Cas no. 110–82-7) in support of summary information on the Integrated Risk Information System (IRIS). (635R03008). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1005tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005a). Integrated Risk Information System (IRIS): Chemical assessment summary for toluene (CASRN 108–88-3). Washington, DC. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0118_summary.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2005b). Toxicological review of n-hexane (CAS no. 110–54-3) in support of summary information on the Integrated Risk Information System (IRIS) [EPA Report]. (EPA/635/R-03/012). https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0486tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2006). 2006 Edition of the drinking water standards and health advisories [EPA Report]. (EPA/822/R-06/013). Washington, DC. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1004X78.txt
U.S. EPA (U.S. Environmental Protection Agency). (2007a). Concepts, methods, and data sources for cumulative health risk assessment of multiple chemicals, exposures, and effects: A resource document [EPA Report]. (EPA/600/R-06/013F). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=190187
U.S. EPA (U.S. Environmental Protection Agency). (2007b). High production volume (HPV) challenge program: Sponsored chemicals list. Washington, DC. http://www.epa.gov/hpv/pubs/update/spnchems.htm
U.S. EPA (U.S. Environmental Protection Agency). (2007c). Provisional peer-reviewed toxicity values for 2-methylnaphthalene (CASRN 91–57-6) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Methylnaphthalene2.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2007d). Provisional peer-reviewed toxicity values for pyrene (CASRN 129–00-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Pyrene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2008). Provisional peer-reviewed toxicity values for 1-methylnaphthalene (CASRN 90–12-0) [EPA Report]. (EPA/690/R-08/017F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/recordisplay.cfm?deid=338997
U.S. EPA (U.S. Environmental Protection Agency). (2009a). Provisional peer-reviewed provisional subchronic toxicity values for n-hexane (CASRN 110–54-3) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/HexaneN.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009b). Provisional peer-reviewed subchronic toxicity values for toluene (CASRN 108–88-3) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Toluene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009c). Provisional peer-reviewed toxicity values for anthracene (CASRN 120–12-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Anthracene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009d). Provisional peer-reviewed toxicity values for benzene (CASRN 71–43-2): Derivation of a subchronic oral provisional-RfD and a subchronic inhalation provisional-RfC [EPA Report]. (EPA/690/R-09/003F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Benzene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009e). Provisional peer-reviewed toxicity values for commercial or practical grade hexane [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/HexaneCommercial.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009f). Provisional peer-reviewed toxicity values for complex mixtures of aliphatic and aromatic hydrocarbons (CASRN various) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/ComplexMixturesofAliphaticandAromaticH ydrocarbons.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009g). Provisional peer-reviewed toxicity values for ethylbenzene (CASRN 100–41-4) [EPA Report]. (EPA/690/R-090/23F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Ethylbenzene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009h). Provisional peer-reviewed toxicity values for high flash aromatic naphtha (CASRNs 64724–95-6 and 88845–25-4) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/NaphthaHighFlashAromaticHFAN.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009i). Provisional peer-reviewed toxicity values for methylcyclopentane (CASRN 96–37-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Methylcyclopentane.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009j). Provisional peer-reviewed toxicity values for midrange aliphatic hydrocarbon streams [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/MidrangeAliphaticHydrocarbonStreams.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009k). Provisional peer-reviewed toxicity values for n-Decane (CASRN 124–18-5) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Decanen.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009l). Provisional peer-reviewed toxicity values for n-nonane (CASRN 111–84-2) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Nonanen.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009m). Provisional peer-reviewed toxicity values for n-pentane (CASRN 109–66-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Pentanen.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009n). Provisional peer-reviewed toxicity values for n-propylbenzene (CASRN 103–65-1) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Propylbenzenen.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009o). Provisional peer-reviewed toxicity values for phenanthrene (CASRN 85–01-8) [EPA Report]. (EPA690R09045F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Phenanthrene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009p). Provisional peer-reviewed toxicity values for total petroleum hydrocarbons (aliphatic high) [EPA Report]. Cincinnati, OH: National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/pprtv/documents/TotalPetroleumHydrocarbonsAliphaticHigh.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009q). Provisional peer-reviewed toxicity values for total petroleum hydrocarbons (aliphatic medium) [EPA Report]. Cincinnati, OH: National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/pprtv/documents/TotalPetroleumHydrocarbonsAliphaticLow.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009r). Provisional peer-reviewed toxicity values for total petroleum hydrocarbons (aromatic low) [EPA Report]. Cincinnati, OH: National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/pprtv/documents/TotalPetroleumHydrocarbonsAliphaticLow.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009s). Provisional peer-reviewed toxicity values for white mineral oil (CASRN 8012–95-1 and 8020–83-5) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/WhiteMineralOil.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2009t). Provisional peer-reviewed toxicity values for xylenes (CASRN 1330–20-7) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/XyleneMixture.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2010a). Provisional peer-reviewed toxicity values for cyclohexane (CASRN 110–82-7) [EPA Report]. Cincinnati, OH. http://hhpprtv.ornl.gov/issue_papers/Cyclohexane.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2010b). Provisional peer-reviewed toxicity values for n-butylbenzene (CASRN 104–51-8) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Butylbenzenen.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Provisional peer-reviewed toxicity values for 1,1-biphenyl (CASRN 92–52-4) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Biphenyl11.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Provisional peer-reviewed toxicity values for acenaphthene (CASRN 83–32-9) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Acenaphthene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012a). Provisional peer-reviewed toxicity values for cyclohexene (CASRN 110–83-8) [EPA Report]. (EPA690R12010F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Cyclohexene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012b). Provisional peer-reviewed toxicity values for fluoranthene (CASRN 206–44-0) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Fluoranthene.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012c). Provisional peer-reviewed toxicity values for sec-butylbenzene (CASRN 135–98-8) [EPA Report]. (EPA/690/R-12/004F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Butylbenzenesec.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2012d). Provisional peer-reviewed toxicity values for tert-butylbenzene (CASRN 98–06-6) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Butylbenzenetert.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2013a). Provisional peer-reviewed toxicity values for methylcyclohexane (CASRN 108–87-2) [EPA Report]. (EPA690R13015F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Methylcyclohexane.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2013b). Toxicological review of biphenyl (CAS 92–52-4). In support of summary information on the Integrated Risk Information System (IRIS). (EPA/635/R-11/005F). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/risk/hhra/recordisplay.cfm?deid=247853
U.S. EPA (U.S. Environmental Protection Agency). (2015). Provisional peer-reviewed toxicity values for 2,4,4-trimethylpentene (CASRN 25167–70-8) [EPA Report]. (EPA690R15014F). Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/Trimethylpentene244.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Provisional peer-reviewed toxicity values for n-heptane (CASRN 142–82-5) [EPA Report]. Cincinnati, OH. https://cfpub.epa.gov/ncea/pprtv/documents/HeptaneN.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Toxicological review of trimethylbenzenes (CASRNs 25551–13-7, 95–63-6, 526–73-8, and 108–67-8). (EPA/635/R-16/161Fa). U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1037tr.pdf
U.S. EPA (U.S. Environmental Protection Agency). (2017). Toxicological review of benzo[a]pyrene (CASRN 50–32-8): Supplemental information [EPA Report]. (EPA635R17003Fb). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/si/si_public_file_download.cfm?p_download_id=535926&Lab=NCEA
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox chemicals dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Provisional peer-reviewed toxicity values for benzo[e]pyrene (BeP) (CASRN 192–97-2). (EPA/690/R-21/008F). Cincinnati, OH: Center for Public Health and Environmental Assessment.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). Provisional peer-reviewed toxicity values for the aliphatic low carbon range TPH fraction (CASRN various) [EPA Report]. Cincinnati, OH.
U.S. EPA (U.S. Environmental Protection Agency). (2022b). Provisional peer-reviewed toxicity values for the aromatic high carbon range TPH fraction cancer assessment (CASRN various) [EPA Report]. Cincinnati, OH.
U.S. EPA (U.S. Environmental Protection Agency). (2022c). Provisional peer-reviewed toxicity values for the aromatic high carbon range TPH fraction noncancer assessment (CASRN various) [EPA Report]. Cincinnati, OH.
U.S. EPA (U.S. Environmental Protection Agency). (2022d). Provisional peer-reviewed toxicity values for the aromatic medium carbon range TPH fraction (CASRN various) [EPA Report]. Cincinnati, OH.
Wang NC Y; Rice GE; Teuschler LK; Colman J; Yang RS H. (2012). An in silico approach for evaluating a fraction-based, risk assessment method for total petroleum hydrocarbon mixtures. J Toxicol 2012: 410143. 10.1155/2012/410143 22496687
Weisman WH. (1998). Total petroleum hydrocarbon criteria working group: A risk-based approach for the management of total petroleum hydrocarbons in soil. Journal of Soil Contamination 7: 1–15.
Wynder EL; Hoffmann D. (1959). A study of tobacco carcinogenesis. VII. The role of higher polycyclic hydrocarbons. Cancer 12: 1079–1086. 10.1002/1097-0142(195911/12)12:6<1079::aid-cncr2820120604>3.0.co;2-i 13846285
Yan Z; Zhang H; Maher C; Arteaga-Solis E; Champagne FA; Wu L; McDonald JD; Yan B; Schwartz GJ; Miller RL. (2014). Prenatal polycyclic aromatic hydrocarbon, adiposity, peroxisome proliferator-activated receptor (PPAR) γ methylation in offspring, grand-offspring mice. PLoS ONE 9: e110706. 10.1371/journal.pone.0110706 25347678