# APPENDIX A CHEMICAL SYNONYMS AND ABBREVIATIONS

Table A-1 Chemical Synonyms and Abbreviations

Chemical Name (common synonyms^a^) | CASRN | Abbreviation | Structure | Molecular Weight (g/mol)
Aromatic High Carbon Range
1,1-Biphenyl; (biphenyl; 1,1′-biphenyl; 1,1-biphenyl) | 92-52-4 | BH | Chemical symbol for 1,1-Biphenyl | 154.212
1-Methylnaphthalene; (naphthalene, 1-methyl-) | 90-12-0 | 1MeNPT | Chemical symbol for 1-Methylnaphthalene | 142.201
2-Methylnaphthalene; (naphthalene, 2-methyl-) | 91-57-6 | 2MeNPT | Chemical symbol for 2-Methylnaphthalene | 142.201
Acenaphthene; (acenaphthylene, 1,2-dihydro-; 1,2-dihydroacenaphthylene; 1,8-ethylenenaphthalene) | 83-32-9 | ANL | Chemical symbol for Acenaphthene | 154.212
Anthracene; (anthracin; paranaphthalene) | 120-12-7 | AC | Chemical symbol for Anthracene | 178.234
Benz[e]acephenanthrylene; (benzo[b]fluoranthene; benzo[e]fluoranthene; benzo[e]acephenanthrylene; 3,4-benz[e]acephenanthrylene; 2,3-benzofluoranthene; 3,4-benzofluoranthene) | 205-99-2 | BeAPE | Chemical symbol for Benz[e]acephenanthrylene | 252.316
Benz[a]anthracene; (tetraphene; benzo[b]phenanthrene; 1,2-benzanthracene; 2,3-benzophenanthrene; 1,2-benzanthrene; naphthanthracene) | 56-55-3 | BaAC | Chemical symbol for Benz[a]anthracene | 228.294
Benzo[k]fluoranthene; (dibenzo[b,jk]fluorene; 8,9-benzofluoranthene; 11,12-benzofluoranthene; 2,3:1′,8′-biaphthylene) | 207-08-9 | BkFA | Chemical symbol for Benzo[k]fluoranthene | 252.316
Benzo[a]pyrene; (benzo[pqr]tetraphene; benzo[def]chrysene; 1,2-benzpyrene;benzene 3,4-benzopyren; 4,5-benzpyrene; 6,7-benzopyrene) | 50-32-8 | BaP | Chemical symbol for Benzo[a]pyrene | 252.316
Benzo[e]pyrene | 192-97-2 | BeP | Chemical symbol for Benzo[e]pyrene | 252.316
Chrysene; (benzo[a]phenanthrene; 1,2-benzophenanthrene) | 218-01-9 | CH | Chemical symbol for Chrysene | 228.294
Dibenz[a,h]anthracene; (benzo[k]tetraphene; 1,2:5,6-dibenzoanthracene; 1,2:5,6-benzanthracene; 1,2:5,6-benz[a]anthracene) | 53-70-3 | DBahAC | Chemical symbol for Dibenz[a,h]anthracene | 278.354
Fluoranthene; (clustercarbon; idryl; benzo [jk]fluorene; 1,2-[1,8-naphthalenediyl]benzene; benz[a]acenaphthylene; 1,2-benzoacenaphyhylene) | 206-44-0 | FA | Chemical symbol for Fluoranthene | 202.256
Fluorene; (9H-fluorene; 2,3-benzidene; o-biphenylenemethane; diphenylenemethane; 2,2’-methylenebiphenyl; o-biphenylmethane) | 86-73-7 | FE | Chemical symbol for Fluorene | 166.223
Indeno[1,2,3cd]pyrene; (o-phenylenepyrene; 1,10-[o-phenylene]pyrene; 1,10-[1,2-phenylene]pyrene; 2,3-[o-phenylene]pyrene; 2,3-phenylenepyrene) | 193-39-5 | I123cdP | Chemical symbol for Indeno[1,2,3cd]pyrene | 276.338
Naphthalene; (naphthalin) | 91-20-3 | NPT | Chemical symbol for Naphthalene | 128.174
Pyrene; (benzo[def]phenanthrene; pyren) | 129-00-0 | Pyr | Chemical symbol for Pyrene | 202.256
Aromatic Medium Carbon Range
1,2,3-Trimethylbenzene; (benzene, 1,2,3-trimethyl-) | 526-73-8 | 1,2,3-TMB | Chemical symbol for 1,2,3-Trimethylbenzene | 120.195
1,2,4-Trimethylbenzene; (benzene, 1,2,4-trimethyl-) | 95-63-6 | 1,2,4-TMB | Chemical symbol for 1,2,4-Trimethylbenzene | 120.195
1,3,5-Trimethylbenzene; (benzene, 1,3,5-trimethyl-) | 108-67-8 | 1,3,5-TMB | Chemical symbol for 1,3,5-Trimethylbenzene | 120.195
Isopropylbenzene; (cumene; [propan-2-yl]benzene; benzene, [1-methylethyl]-) | 98-82-8 | | Chemical symbol for Isopropylbenzene | 120.195
HFAN; (light aromatic solvent naphtha [petroleum]; solvent naphtha, petroleum, light aromatic; super high flash naphtha; aromatic solvent; solvent, aromatic petroleum; solvent naphtha; light aromatic solvent naphtha; low boiling point naphtha–unspecified; solvent naphtha [petroleum], light aromatic) | 64742-95-6 | | Various | Various
n-Butylbenzene; (benzene, butyl-) | 104-51-8 | | Chemical symbol for n-Butylbenzene | 134.222
n-Propylbenzene; (propylbenzene; benzene, propyl-) | 103-65-1 | | Chemical symbol for n-Propylbenzene | 120.195
sec-Butylbenzene; ([butan-2-yl]benzene; benzene, [1-methylpropyl]-) | 135-98-8 | | Chemical symbol for sec-Butylbenzene | 134.222
tert-Butylbenzene; (benzene, [1,1-dimethylethyl]-) | 98-06-6 | | Chemical symbol for tert-Butylbenzene | 134.222
Aliphatic Low Carbon Range
2,4,4-Trimethylpentene | 2516-77-08 (mixture of two isomers, 107-39-1 and 107-40-4) | | Chemical symbol for 2,4,4-Trimethylpentene | 112.22
Commercial hexane; (NOCAS_872521) | Various | | Various | Various
Cyclohexane | 110-82-7 | | Chemical symbol for Cyclohexane | 84.162
Cyclohexene | 110-83-8 | | Chemical symbol for Cyclohexene | 82.146
n-Heptane; (heptane) | 142-82-5 | | Chemical symbol for n-Heptane | 100.205
n-Hexane; (hexane) | 110-54-3 | | Chemical symbol for n-Hexane | 86.178
n-Pentane; (pentane; norpar 55) | 109-66-0 | | Chemical symbol for n-Pentane | 72.151
Methylcyclopentane; (cyclopentane, methyl-) | 96-37-7 | | Chemical symbol for Methylcyclopentane | 84.162

a Synonyms are listed according to National Institute of Standards and Technology (NIST, 2020) and include valid synonyms from U.S. EPA CompTox Chemicals Dashboard; accessed 03-30-2020 (U.S. EPA, 2021a).

U.S. EPA = U.S. Environmental Protection Agency.